# List of Excluded Studies

Reasons for Exclusion:

X-1: Does not include participants with ASD ages 2–12 or 0–2 at risk for ASD

X-2: Is not original research

X-3: Has <10 participants; <30 in medical interventions

X-4: Not applicable to any key questions

X-5: Not published in English

X-6: Does not have extractable data; only presents individual participant data; missing pages

X-10: Published before 2000

1 What is a reasonable cost of appropriate education?. J Autism Dev Disord. 12. 1980;10(4):459-72. X-2, X-4,X-10. [pmid: 6821494].
2 Sex education and sexual awareness building for autistic children and youth: some viewpoints and considerations. J Autism Dev Disord. 06. 1985;15(2):213-27. X-1, X-2, X-3, X-4, X-10. [pmid: 3997748].
3 Community care: suffering acts of omission. Nurs Stand. 06. 17–23. 1992;6(39):50-1. X-4, X-10.
4 Position of the American Dietetic Association: nutrition in comprehensive program planning for persons with developmental disabilities. J Am Diet Assoc. 05. 1992;92(5):613-5. X-10. [pmid: 1374088].
5 Auditory integration training. ASHA. 11. 1994;36(11):55-8. X-10.
6 Auditory integration training and facilitated communication for autism. American Academy of Pediatrics. Committee on Children with Disabilities. Pediatrics. 08. 1998;102(2 Pt 1):431-3. X-1, X-2, X-3, X-4, X-10. [pmid: 9685446].
7 MMR vaccine coverage shows signs of recovery. Commun Dis Rep CDR Wkly. 09. 24. 1999;9(39):345. X-1. X-2, X-3, X-4, X-10. [pmid: 10510563].
8 Significant achievement award. A comprehensive program for treating profoundly autistic children--Center for Autistic Children, Philadelphia. Psychiatr Serv. 11. 2000;51(11):1439-40. X-1, X-2, X-3, X-4. [pmid: 11058194].
9 American Academy of Pediatrics: Counseling families who choose complementary and alternative medicine for their child with chronic illness or disability. Committee on Children With Disabilities. Pediatrics. 03. 2001;107(3):598-601. X-1, X-2, X-3, X-4. [pmid: 11230608].
10 Autism and Lovaas treatment: a systematic review of effectiveness evidence. Int J Technol Assess Health Care. Spring. 2001;17(2):252. X-1, X-2, X-3, X-4. [pmid: 11446138].
11 JAMA patient page. Autistic disorder. JAMA. 04. 4. 2001;285(13):1798. X-1, X-2, X-3, X-4. [pmid: 11302153].
12 Technical report: the pediatrician’s role in the diagnosis and management of autistic spectrum disorder in children. Pediatrics. 05. 2001;107(5):E85. X-1, X-2, X-3, X-4. [pmid: 11331735].
13 Is there a link between MMR vaccine and autism?...and an expert’s commentary. Child Health Alert. 12. 2002;20:1-2. X-1, X-2, X-3, X-4.
14 Science finds no link between MMR vaccine and autism. Mich Med. 09–10. 2002;101(5):37. X-1, X-2, X-3, X-4. [pmid: 12645252].
15 Autism: neural basis and treatment possibilities. Symposium proceedings. London, United Kingdom. 18–20 June 2002. Novartis Found Symp. 2003;251:1-310. X-1, X-2, X-3, X-4.
16 MMR vaccine--how effective and how safe?. Drug Ther Bull. 04. 2003;41(4):25-9. X-1, X-2, X-3, X-4. [pmid: 12724845].
17 Autism: a new treatment seems unsuccessful. Child Health Alert. 02. 2004;22:1-2. X-1, X-2, X-3, X-4.
18 Asperger’s syndrome. Harv Ment Health Lett. 02. 2005;21(8):4-5. X-1, X-2, X-3, X-4.
19 Global Advisory Committee on Vaccine Safety. 2–3 December 2004. Wkly Epidemiol Rec. 01. 7. 2005;80(1):3-7. X-1, X-2, X-3, X-4.
20 Risperidone: new indication. Behavioural disorders in children with autism or mental disabilities: no progress. Prescrire Int. 04. 2006;15(82):43-5. X-1, X-2, X-3, X-4. [pmid: 16602211].
21 Searching for early signs of autism spectrum disorders. Researchers seek to identify biomarkers and behaviors to enable earlier diagnosis. Harv Ment Health Lett. 11. 2007;24(5):4-5. X-1, X-2, X-3, X-4.
22 Words and Concepts. What Works Clearinghouse Intervention Report. [142 Reports: Evaluative]. Dec. What Works Clearinghouse. 2007:14. X-1, X-2, X-3, X-4.
23 Bibliography. Current world literature. Developmental disorders. Curr Opin Neurol. 04. 2008;21(2):202-13. X-1, X-2, X-3, X-4. [pmid: 18317281].
24 Inter-agency working. Unlock the full spectrum of care. Health Serv J. 02. 5. 2009;119(6142):24-5. X-1, X-2, X-3, X-4.
25 Rare diseases offer insights into autism spectrum disorders. Preliminary laboratory studies suggest new biological targets for intervention. Harv Ment Health Lett. 04. 2009;25(10):3. X-1, X-2, X-3, X-4. [pmid: 19475765].
26 Special report: aCGH for the genetic evaluation of patients with developmental delay/mental retardation or autism spectrum disorder. Technol Eval Cent Asses Program Exec Summ. 04. 2009;23(10):1-5. X-1, X-3, X-4.
27 Special report: early intensive behavioral intervention based on applied behavior analysis among children with autism spectrum disorders. Technol Eval Cent Asses Program Exec Summ. 02. 2009;23(9):1-5. X-1, X-2, X-3.
28 What is Asperger syndrome?. J Pract Nurs. Summer. 2009;59(2):25. X-1, X-2, X-3, X-4. [pmid: 19719004].
29 What is autism?. J Pract Nurs. Summer. 2009;59(2):22-4. X-1, X-2, X-3, X-4. [pmid: 19719002].
30 Aarsland D, Ballard C, Walker Z, et al. Memantine in patients with Parkinson’s disease dementia or dementia with Lewy bodies: a double-blind, placebo-controlled, multicentre trial. Lancet Neurol. 07. 2009;8(7):613-8. X-1, X-4. [pmid: 19520613].
31 Aarsland D, Cummings JL, Larsen JP. Neuropsychiatric differences between Parkinson’s disease with dementia and Alzheimer’s disease. Int J Geriatr Psychiatry. 02. 2001;16(2):184-91. X-1, X-4. [pmid: 11241724].
32 Aarsland D, Hutchinson M, Larsen JP. Cognitive, psychiatric and motor response to galantamine in Parkinson’s disease with dementia. Int J Geriatr Psychiatry. 10. 2003;18(10):937-41. X-1, X-4. [pmid: 14533126].
33 Aarsland D, Perry R, Larsen JP, et al. Neuroleptic sensitivity in Parkinson’s disease and parkinsonian dementias. J Clin Psychiatry. 05. 2005;66(5):633-7. X-1, X-2, X-3, X-4. [pmid: 15889951].
34 Abbey D. Helping families find the best evidence: CAM therapies for autism spectrum disorders and Asperger’s Disorder. J Spec Pediatr Nurs. 07. 2009;14(3):200-2. X-1, X-2, X-3, X-4. [pmid: 19614829].
35 Abelson AG. The development of gender identity in the autistic child. Child Care Health Dev. 11–12. 1981;7(6):347-56. X-4, X-10. [pmid: 7326841].
36 Accordino R, Comer R, Heller WB. Searching for Music’s Potential: A Critical Examination of Research on Music Therapy with Individuals with Autism. Research in Autism Spectrum Disorders. 01–03. 2007;1(1):101-115. X-1, X-2, X-3, X-4.
37 Ackland MJ, Wade RW. Health status of Victorian special school children. J Paediatr Child Health. 10. 1995;31(5):423-7. X-1, X-4, X-10. [pmid: 8554863].
38 Acuda SW. Practical therapeutics the management of child psychiatric disorders. East Afr Med J. 01. 1982;59(1):6-10. X-1, X-2, X-3, X-4, X-10. [pmid: 7117180].
39 Adam C, Salomon G, Walther S, et al. Photodynamic diagnosis using 5-aminolevulinic acid for the detection of positive surgical margins during radical prostatectomy in patients with carcinoma of the prostate: a multicentre, prospective, phase 2 trial of a diagnostic procedure. Eur Urol. 06. 2009;55(6):1281-8. X-1, X-3, X-4. [pmid: 19328622].
40 Adamo SMG. An adolescent and his imaginary companions: From quasi-delusional constructs to creative imagination. Journal of Child Psychotherapy. 11. 2004;30(3):275-295. X-3.
41 Adams C, Lloyd J, Aldred C, et al. Exploring the effects of communication intervention for developmental pragmatic language impairments: a signal-generation study. Int J Lang Commun Disord. 01–02. 2006;41(1):41-65. X-1, X-2, X-3, X-4. [pmid: 16272002].
42 Adams JB, George F, Audhya T. Abnormally high plasma levels of vitamin B6 in children with autism not taking supplements compared to controls not taking supplements. J Altern Complement Med. 01–02. 2006;12(1):59-63. X-4. [pmid: 16494569].
43 Adams JB, Holloway C. Pilot study of a moderate dose multivitamin/mineral supplement for children with autistic spectrum disorder. J Altern Complement Med. 12. 2004;10(6):1033-9. X-3. [pmid: 15673999].
44 Adams JB, Romdalvik J, Ramanujam VM, et al. Mercury, lead, and zinc in baby teeth of children with autism versus controls. J Toxicol Environ Health A. 06. 2007;70(12):1046-51. X-4. [pmid: 17497416].
45 Adams L, Conn S. Nutrition and its relationship to autism. Focus on Autism and Other Developmental Disabilities. Spr. 1997;12(1):53-58. X-1, X-2, X-3, X-4, X-10.
46 Adams L, Gouvousis A, VanLue M, et al. Social Story Intervention: Improving Communication Skills in a Child with an Autism Spectrum Disorder. Focus on Autism and Other Developmental Disabilities. 06. 2004;19(2):87-94. X-3.
47 Adamson A, O’Hare A, Graham C. Impairments in Sensory Modulation in Children with Autistic Spectrum Disorder. British Journal of Occupational Therapy. 08. 2006;69(8):357-364. X-4.
48 Adamson LB, Bakeman R, Deckner DF, et al. Joint engagement and the emergence of language in children with autism and Down syndrome. J Autism Dev Disord. 01. 2009;39(1):84-96. X-4. [pmid: 18581223].
49 Addison L, Lerman DC. Descriptive Analysis of Teachers’ Responses to Problem Behavior Following Training. Journal of Applied Behavior Analysis. Sum. 2009;42(2):485-490. X-1, X-3, X-4. [pmid: 19949540].
50 Adelinis JD, Hagopian LP. The use of symmetrical “do” and “don’t” requests to interrupt ongoing activities. Journal of Applied Behavior Analysis. Win. 1999;32(4):519-523. X-1, X-3, X-10. [pmid: 10641305].
51 Adelinis JD, Piazza CC, Goh H-L. Treatment of multiply controlled destructive behavior with food reinforcement. Journal of Applied Behavior Analysis. Spr. 2001;34(1):97-100. X-3. [pmid: 11317997].
52 Adrien JL, Faure M, Perrot A, et al. Autism and family home movies: preliminary findings. J Autism Dev Disord. 03. 1991;21(1):43-9. X-4, X-10. [pmid: 2037548].
53 Adrien JL, Martineau J, Barthelemy C, et al. Disorders of regulation of cognitive activity in autistic children. J Autism Dev Disord. 06. 1995;25(3):249-63. X-4, X-10. [pmid: 7559291].
54 Adrien JL, Rossignol-Deletang N, Martineau J, et al. Regulation of cognitive activity and early communication development in young autistic, mentally retarded, and young normal children. Dev Psychobiol. 09. 2001;39(2):124-36. X-4. [pmid: 11568882].
55 Afzal MA, Ozoemena LC, O’Hare A, et al. Absence of detectable measles virus genome sequence in blood of autistic children who have had their MMR vaccination during the routine childhood immunization schedule of UK. J Med Virol. 05. 2006;78(5):623-30. X-4. [pmid: 16555271].
56 Agosta E, Graetz JE, Mastropieri MA, et al. Teacher-Researcher Partnerships to Improve Social Behavior through Social Stories. Intervention in School and Clinic. 05. 2004;39(5):276-287. X-3.
57 Ahearn WH. Using simultaneous presentation to increase vegetables consumption in a mildly selective child with autism. Journal of Applied Behavior Analysis. Fal. 2003;36(3):361-365. X-3. [pmid: 14596577].
58 Ahearn WH, Clark KM, DeBar R, et al. On the Role of Preference in Response Competition. Journal of Applied Behavior Analysis. Sum. 2005;38(2):247-250. X-3. [pmid: 16033172].
59 Ahearn WH, Clark KM, Gardenier NC, et al. Persistence of stereotypic behavior: examining the effects of external reinforcers. J Appl Behav Anal. Winter. 2003;36(4):439-48. X-3. [pmid: 14768664].
60 Ahearn WH, Clark KM, MacDonald RP, et al. Assessing and treating vocal stereotypy in children with autism. J Appl Behav Anal. Summer. 2007;40(2):263-75. X-3. [pmid: 17624067].
61 Ahn HS, DiAngelo DJ. A biomechanical study of artificial cervical discs using computer simulation. Spine. 04. 15. 2008;33(8):883-92. X-1, X-2, X-3, X-4. [pmid: 18404108].
62 Ahuja SD, Stroup SL, Bolin MG. Evaluation of tissue-air ratios and tissue-maximum ratios with the photon energy-fluence absorption dose model. Med Phys. 03–04. 1981;8(2):215-9. X-1, X-2, X-3, X-4, X-10. [pmid: 6798386].
63 Ahumada JL. What is a clinical fact? Clinical psychoanalysis as inductive method. International Journal of Psycho-Analysis. 12. 1994;75(5–6):949-962. X-1, X-2, X-3, X-4, X-10. [pmid: 7713672].
64 Aiken JM, Salzberg CL. The effects of a sensory extinction procedure on stereotypic sounds of two autistic children. Journal of Autism and Developmental Disorders. 09. 1984;14(3):291-299. X-3, X-10. [pmid: 6480547].
65 Akmanoglu N, Batu S. Teaching Pointing to Numerals to Individuals with Autism Using Simultaneous Prompting. Education and Training in Developmental Disabilities. 12. 2004;39(4):326-336. X-3.
66 Akmanoglu-Uludag N, Batu S. Teaching naming relatives to individuals with autism using simultaneous prompting. Education and Training in Developmental Disabilities. 12. 2005;40(4):401-410. X-3.
67 Alamy SS, Jarskog LF, Sheitman BB, et al. Secretin in a patient with treatment-resistant schizophrenia and prominent autistic features. Schizophrenia Research. 02. 2004;66(2–3):183-186. X-1, X-3, X-4. [pmid: 15061252].
68 Alanay Y, Unal F, Turanli G, et al. A multidisciplinary approach to the management of individuals with fragile X syndrome. J Intellect Disabil Res. 02. 2007;51(Pt 2):151-61. X-1, X-3, X-4. [pmid: 17217479].
69 Alberti A, Pirrone P, Elia M, et al. Sulphation deficit in “low-functioning” autistic children: a pilot study. Biol Psychiatry. 08. 1. 1999;46(3):420-4. X-4, X-10. [pmid: 10435209].
70 Albertini G, Polito E, Sara M, et al. Compulsive masturbation in infantile autism treated by mirtazapine. Pediatr Neurol. 05. 2006;34(5):417-8. X-3. [pmid: 16648008].
71 Alcantara PR. Effects of videotape instructional package on purchasing skills of children with autism. Exceptional Children. 09. 1994;61(1):40-55. X-10.
72 Alden NE, Rabbitts A, Rolls JA, et al. Burn injury in patients with early-onset neurological impairments: 2002 ABA paper. J Burn Care Rehabil. 01–02. 2004;25(1):107-11. X-1, X-3, X-4. [pmid: 14726747].
73 Alderman C. Community care: integration is beautiful. Nurs Stand. 02. 12–18. 1992;6(21):20-1. X-10.
74 Alderman C. Inclusion zone. Nurs Stand. 11. 24–30. 1999;14(10):16-7. X-10.
75 Aldred C, Pollard C, Adams C. Child’sTalk: For children with autism and pervasive developmental disorder. International Journal of Language & Communication Disorders. 2001;36(Suppl):469-474. X-1, X-2, X-3. [pmid: 11340834].
76 Aldred C, Pollard C, Phillips R, et al. Multidisciplinary social communication intervention for children with autism and pervasive developmental disorder: The Child’s Talk project. Educational and Child Psychology. 2001;18(2):76-87. X-1, X-2, X-3, X-4.
77 Aldred CR, Green J. Early social communication interventions for autism. Br J Hosp Med (Lond). 03. 2009;70(3):143-5. X-1, X-2, X-3, X-4. [pmid: 19274002].
78 Alexander RT, Michael DM, Gangadharan SK. The Use of Risperidone in Adults with Asperger Syndrome. British Journal of Developmental Disabilities. 2004;50(99,Pt2):109-115. X-1, X-3.
79 Alfredsson G, Harnryd C, Wiesel FA. Effects of sulpiride and chlorpromazine on autistic and positive psychotic symptoms in schizophrenic patients--relationship to drug concentrations. Psychopharmacology (Berl). 1985;85(1):8-13. X-1, X-4, X-10. [pmid: 3920702].
80 Ali SM, Olivo M. Bio-distribution and subcellular localization of Hypericin and its role in PDT induced apoptosis in cancer cells. Int J Oncol. 09. 2002;21(3):531-40. X-1, X-4. [pmid: 12168096].
81 Allan L, McKeith I, Ballard C, et al. The prevalence of autonomic symptoms in dementia and their association with physical activity, activities of daily living and quality of life. Dement Geriatr Cogn Disord. 2006;22(3):230-7. X-1, X-2, X-3, X-4. [pmid: 16902277].
82 Allan LM, Ballard CG, Rowan EN, et al. Incidence and prediction of falls in dementia: a prospective study in older people. PLoS One. 2009;4(5):e5521. X-1, X-4. [pmid: 19436724].
83 Allen D, Evans C, Hider A, et al. Offending Behaviour in Adults with Asperger Syndrome. Journal of Autism and Developmental Disorders. 04. 2008;38(4):748-758. X-1, X-4. [pmid: 17805955].
84 Allen DA, Affleck G, McQueeney M, et al. Validation of the parent behavior progression in an early intervention program. Ment Retard. 08. 1982;20(4):159-63. X-1, X-4, X-10. [pmid: 7144556].
85 Allen DA, Mendelson L. Parent, child, and professional: Meeting the needs of young autistic children and their families in a multidisciplinary therapeutic nursery model. Psychoanalytic Inquiry. Special Issue: Autistic spectrum disorders and psychoanalytic ideas: Reassessing the fit. 2000;20(5):704-731. X-3.
86 Allen DG, Lowe K, Moore K, et al. Predictors, costs and characteristics of out of area placement for people with intellectual disability and challenging behaviour. J Intellect Disabil Res. 06. 2007;51(Pt. 6):409-16. X-1, X-4. [pmid: 17493024].
87 Allgood N. Parents’ perceptions of family-based group music therapy for children with autism spectrum disorders. Music Therapy Perspectives. 2005;23(2):92-99. X-1, X-3, X-4.
88 Allik H, Larsson JO, Smedje H. Insomnia in school-age children with Asperger syndrome or high-functioning autism. BMC Psychiatry. 2006;6:18. X-4. [pmid: 16646974].
89 Allison DB, Basile VC, MacDonald RB. Brief report: comparative effects of antecedent exercise and lorazepam on the aggressive behavior of an autistic man. J Autism Dev Disord. 03. 1991;21(1):89-94. X-1, X-3, X-10. [pmid: 2037553].
90 Alonim H. The Mifne Method--ISRAEL: Early intervention in the treatment of autism/PDD: A therapeutic programme for the nuclear family and their child. Journal of Child and Adolescent Mental Health. 2004;16(1):39-43. X-1, X-2, X-3, X-4.
91 Alpern CS, Zager D. Addressing Communication Needs of Young Adults with Autism in a College-Based Inclusion Program. Education and Training in Developmental Disabilities. 12. 2007;42(4):428-436. X-1, X-2, X-3, X-4.
92 Al-Shammari Z. Special Education Teachers’ Attitudes toward Autistic Students in the Autism School in the State of Kuwait: A Case Study. Journal of Instructional Psychology. 09. 2006;33(3):170-178. X-1, X-3, X-4.
93 Altschuler EL. Play with online virtual pets as a method to improve mirror neuron and real world functioning in autistic children. Med Hypotheses. 2008;70(4):748-9. X-1, X-2, X-3, X-4. [pmid: 17826922].
94 Alvarez A. The problem of neutrality: Some reflections on the psychoanalytic attitude in the treatment of borderline and psychotic children. Journal of Child Psychotherapy. 1985;11(1):87-103. X-1, X-2, X-3, X-4, X-10.
95 Alvarez A. Making the thought thinkable: On introjection and projection. Psychoanalytic Inquiry. 1993;13(1):103-122. X-1, X-2, X-3, X-4, X-10.
96 Alvin J. A research project-Martin. Nordic Journal of Music Therapy. 2000;9(1):50-59. X-3.
97 Aly H. Preemptive strike in the war on pain: is it a safe strategy for our vulnerable infants?. Pediatrics. 11. 2004;114(5):1335-7. X-1, X-2, X-3, X-4. [pmid: 15520116].
98 Aman MG. Management of hyperactivity and other acting-out problems in patients with autism spectrum disorder. Semin Pediatr Neurol. 09. 2004;11(3):225-8. X-1, X-2, X-3. [pmid: 15575418].
99 Aman MG, Armstrong SA. Regarding secretin for treating autistic disorder. Journal of Autism and Developmental Disorders. 02. 2000;30(1):71-72. X-3. [pmid: 10819123].
100 Aman MG, De Smedt G, Derivan A, et al. Double-blind, placebo-controlled study of risperidone for the treatment of disruptive behaviors in children with subaverage intelligence. Am J Psychiatry. 08. 2002;159(8):1337-46. X-1, X-3, X-4. [pmid: 12153826].
101 Aman MG, Lam KS, Collier-Crespin A. Prevalence and patterns of use of psychoactive medicines among individuals with autism in the Autism Society of Ohio. J Autism Dev Disord. 10. 2003;33(5):527-34. X-4. [pmid: 14594332].
102 Aman MG, Lam KS, Van Bourgondien ME. Medication patterns in patients with autism: temporal, regional, and demographic influences. J Child Adolesc Psychopharmacol. 02. 2005;15(1):116-26. X-4. [pmid: 15741793].
103 Aman MG, Langworthy KS. Pharmacotherapy for hyperactivity in children with autism and other pervasive developmental disorders. J Autism Dev Disord. 10. 2000;30(5):451-9. X-1, X-2, X-3. [pmid: 11098883].
104 Aman MG, Van Bourgondien ME, Wolford PL, et al. Psychotropic and anticonvulsant drugs in subjects with autism: prevalence and patterns of use. J Am Acad Child Adolesc Psychiatry. 12. 1995;34(12):1672-81. X-4, X-10. [pmid: 8543539].
105 Ambrosini PJ, Elia J, Rynn MA. 49th Annual Meeting of the American Academy of Child & Adolescent Psychiatry. 22–27 October 2002. San Francisco, CA, USA. Expert Opin Pharmacother. 04. 2003;4(4):591-4. X-1, X-2, X-3, X-4.
106 Amir N, Gross-Tsur V. Paradoxical normalization in childhood epilepsy. Epilepsia. 09–10. 1994;35(5):1060-4. X-1, X-3, X-4, X-10. [pmid: 7925152].
107 Amminger GP, Berger GE, Schafer MR, et al. Omega-3 fatty acids supplementation in children with autism: a double-blind randomized, placebo-controlled pilot study. Biol Psychiatry. 02. 15. 2007;61(4):551-3. X-3. [pmid: 16920077].
108 Anagnostou E, Esposito K, Soorya L, et al. Divalproex versus placebo for the prevention of irritability associated with fluoxetine treatment in autism spectrum disorder. J Clin Psychopharmacol. 08. 2006;26(4):444-6. X-3. [pmid: 16855475].
109 Anckarsater H, Nilsson T, Saury JM, et al. Autism spectrum disorders in institutionalized subjects. Nord J Psychiatry. 2008;62(2):160-7. X-4. [pmid: 18569781].
110 Anderson CM, Long ES. Use of a structured descriptive assessment methodology to identify variables affecting problem behavior. Journal of Applied Behavior Analysis. Sum. 2002;35(2):137-154. X-3, X-4. [pmid: 12102134].
111 Anderson CM, McMillan K. Parental use of escape extinction and differential reinforcement to treat food selectivity. Journal of Applied Behavior Analysis. Win. 2001;34(4):511-515. X-3. [pmid: 11800192].
112 Anderson DK, Oti RS, Lord C, et al. Patterns of Growth in Adaptive Social Abilities among Children with Autism Spectrum Disorders. Journal of Abnormal Child Psychology. 10. 2009;37(7):1019-1034. X-4. [pmid: 19521762].
113 Anderson GM, Freedman DX, Cohen DJ, et al. Whole blood serotonin in autistic and normal subjects. J Child Psychol Psychiatry. 11. 1987;28(6):885-900. X-4, X-10. [pmid: 3436995].
114 Anderson LT, Campbell M, Adams P, et al. The effects of haloperidol on discrimination learning and behavioral symptoms in autistic children. J Autism Dev Disord. 06. 1989;19(2):227-39. X-10. [pmid: 2663834].
115 Anderson LT, Campbell M, Grega DM, et al. Haloperidol in the treatment of infantile autism: effects on learning and behavioral symptoms. Am J Psychiatry. 10. 1984;141(10):1195-202. X-10. [pmid: 6385731].
116 Anderson S, Hanson R, Malecha M, et al. The effectiveness of naltrexone in treating task attending, aggression, self-injury and stereotypic mannerisms of six young males with autism or pervasive developmental disorders. Journal of Developmental and Physical Disabilities. 09. 1997;9(3):211-242. X-1, X-3, X-10.
117 Anderson SR, Avery DL, DiPietro EK, et al. Intensive home-based early intervention with autistic children. Education & Treatment of Children. Special Issue: New developments in the treatment of persons exhibiting autism and severe behavior disorders. 11. 1987;10(4):352-366. X-10.
118 Ando H, Yoshimura I, Wakabayashi S. Effects of age on adaptive behavior levels and academic skill levels in autistic and mentally retarded children. J Autism Dev Disord. 06. 1980;10(2):173-84. X-4, X-10. [pmid: 6927685].
119 Andreae MC, Freed GL, Katz SL. Safety concerns regarding combination vaccines. Perspective of select European countries. Hum Vaccin. 01–02. 2005;1(1):1-5. X-1, X-2, X-3, X-4. [pmid: 17038825].
120 Andrews N, Miller E, Taylor B, et al. Recall bias, MMR, and autism. Arch Dis Child. 12. 2002;87(6):493-4. X-1, X-3, X-4. [pmid: 12456546].
121 Andrews R, Wyver S. Autistic Tendencies: Are There Different Pathways for Blindness and Autism Spectrum Disorder?. British Journal of Visual Impairment. 2005;23(2):52-57. X-1, X-2, X-3, X-4.
122 Angermeier K, Schlosser RW, Luiselli JK, et al. Effects of Iconicity on Requesting with the Picture Exchange Communication System in Children with Autism Spectrum Disorder. Research in Autism Spectrum Disorders. 07–09. 2008;2(3):430-446. X-3.
123 Anglesea MM, Hoch H, Taylor BA. Reducing rapid eating in teenagers with autism: use of a pager prompt. J Appl Behav Anal. Spring. 2008;41(1):107-11. X-1, X-3. [pmid: 18468283].
124 Anson HM, Todd JT, Cassaretto KJ. Replacing overt verbal and gestural prompts with unobtrusive covert tactile prompting for students with autism. Behavior Research Methods. 11. 2008;40(4):1106-1110. X-3. [pmid: 19001402].
125 Aoi T, Takashima H, Takada T, et al. Fragile X chromosome in institutionalized male adults with mental retardation. Keio J Med. 03. 1989;38(1):36-9. X-1, X-2, X-3, X-4, X-10. [pmid: 2785613].
126 Apple AL, Billingsley F, Schwartz IS. Effects of Video Modeling Alone and With Self-Management on Compliment-Giving Behaviors of Children with High-Functioning ASD. Journal of Positive Behavior Interventions. Win. 2005;7(1):33-46. X-3.
127 Arbelle S, Benjamin J, Golin M, et al. Relation of shyness in grade school children to the genotype for the long form of the serotonin transporter promoter region polymorphism. Am J Psychiatry. 04. 2003;160(4):671-6. X-1, X-4. [pmid: 12668354].
128 Arco L. Improving program outcome with process-based feedback. Journal of Organizational Behavior Management. 1997;17(1):37-64. X-3, X-10.
129 Arco L, Millett R. Maintaining instructional behavior after on-the-job training with process-based performance feedback. Behav Modif. 07. 1996;20(3):300-20. X-1, X-10. [pmid: 8779639].
130 Argott P, Townsend DB, Sturmey P, et al. Increasing the Use of Empathic Statements in the Presence of a Non-Verbal Affective Stimulus in Adolescents with Autism. Research in Autism Spectrum Disorders. 04–06. 2008;2(2):341-352. X-1, X-3.
131 Arnal L, Fazzio D, Martin GL, et al. Instructing university students to conduct discrete-trials teaching with confederates simulating children with autism. Developmental Disabilities Bulletin. 2007;35(1–2):131-137. X-1, X-4.
132 Arndorfer RE, Miltenberger RG, Woster SH, et al. Home-based descriptive and experimental analysis of problem behaviors in children. Topics in Early Childhood Special Education. Spr. 1994;14(1):64-87. X-3, X-10.
133 Arnold GL, Hyman SL, Mooney RA, et al. Plasma amino acids profiles in children with autism: potential risk of nutritional deficiencies. J Autism Dev Disord. 08. 2003;33(4):449-54. X-4. [pmid: 12959424].
134 Arnold LE, Aman MG, Cook AM, et al. Atomoxetine for hyperactivity in autism spectrum disorders: placebo-controlled crossover pilot trial. J Am Acad Child Adolesc Psychiatry. 10. 2006;45(10):1196-205. X-3. [pmid: 17003665].
135 Arnold LE, Aman MG, Martin A, et al. Assessment in multisite randomized clinical trials of patients with autistic disorder: the Autism RUPP Network. Research Units on Pediatric Psychopharmacology. J Autism Dev Disord. 04. 2000;30(2):99-111. X-1, X-2, X-3, X-4. [pmid: 10832774].
136 Arntzen E, Gilde K, Pedersen E. Generalized schedule following in a youth with autism. Scandinavian Journal of Behaviour Therapy. 1998;27(3):135-141. X-1, X-3, X-10.
137 Arntzen E, Tonnessen IR, Brouwer G. Reducing aberrant verbal behavior by building a repertoire of rational verbal behavior. Behavioral Interventions. 07. 2006;21(3):177-193. X-1, X-3, X-4.
138 Arthi K, Tamilarasi A. Prediction of autistic disorder using neuro fuzzy system by applying ANN technique. Int J Dev Neurosci. 11. 2008;26(7):699-704. X-1, X-2, X-3, X-4. [pmid: 18706991].
139 Arvans RK, LeBlanc LA. Functional assessment and treatment of migraine reports and school absences in an adolescent with Asperger’s disorder. Education and Treatment of Children. 02. 2009;32(1):151-166. X-1, X-3, X-4.
140 Askalan R, Mackay M, Brian J, et al. Prospective preliminary analysis of the development of autism and epilepsy in children with infantile spasms. J Child Neurol. 03. 2003;18(3):165-70. X-1, X-3, X-4. [pmid: 12731640].
141 Askmark H, Wiholm BE. Epidemiology of adverse reactions to carbamazepine as seen in a spontaneous reporting system. Acta Neurol Scand. 02. 1990;81(2):131-40. X-1, X-2, X-3, X-4, X-10. [pmid: 2327233].
142 Asmus JM, Franzese JC, Conroy MA, et al. Clarifying Functional Analysis Outcomes for Disruptive Behaviors by Controlling Consequence Delivery for Stereotypy. School Psychology Review. 2003;32(4):624-630. X-3.
143 Assouline SG, Nicpon MF, Doobay A. Profoundly Gifted Girls and Autism Spectrum Disorder: A Psychometric Case Study Comparison. Gifted Child Quarterly. 2009;53(2):89-105. X-3, X-4.
144 Aston-Jones G, Rajkowski J, Cohen J. Locus coeruleus and regulation of behavioral flexibility and attention. Prog Brain Res. 2000;126:165-82. X-1, X-2, X-3, X-4. [pmid: 11105646].
145 Athens ES, Vollmer TR, Sloman KN, et al. An Analysis of Vocal Stereotypy and Therapist Fading. Journal of Applied Behavior Analysis. Sum. 2008;41(2):291-297. X-3. [pmid: 18595296].
146 Atkinson RP, Jenson WR, Rovner L, et al. Brief report: validation of the autism reinforcer checklist for children. J Autism Dev Disord. 12. 1984;14(4):429-33. X-10. [pmid: 6520095].
147 Atlas JA. Play in assessment and intervention in the childhood psychoses. Child Psychiatry & Human Development. Win. 1990;21(2):119-133. X-10. [pmid: 2249494].
148 Atlas JA, Gerbino-Rosen G. Differential diagnostic and treatment of an inpatient adolescent showing pervasive developmental disorder and mania. Psychological Reports. 08. 1995;77(1):207-210. X-1, X-3, X-10. [pmid: 7501761].
149 Attwood T. Unusual behaviours associated with autism. Health Visit. 11. 1993;66(11):402-3. X-10. [pmid: 8276606].
150 Attwood T. Frameworks for behavioral interventions. Child Adolesc Psychiatr Clin N Am. 01. 2003;12(1):65-86. vi. X-1, X-2, X-3, X-4. [pmid: 12512399].
151 August GJ, Raz N, Baird TD. Effects of fenfluramine on behavioral, cognitive, and affective disturbances in autistic children. J Autism Dev Disord. 03. 1985;15(1):97-107. X-10. [pmid: 3884585].
152 August GJ, Raz N, Baird TD. Fenfluramine response in high and low functioning autistic children. J Am Acad Child Adolesc Psychiatry. 05. 1987;26(3):342-6. X-10. [pmid: 3298200].
153 August GJ, Raz N, Papanicolaou AC, et al. Fenfluramine treatment in infantile autism. Neurochemical, electrophysiological, and behavioral effects. J Nerv Ment Dis. 10. 1984;172(10):604-12. X-10. [pmid: 6384430].
154 Avdi E. Negotiating a pathological identity in the clinical dialogue: discourse analysis of a family therapy. Psychol Psychother. 12. 2005;78(Pt 4):493-511. X-3. [pmid: 16354441].
155 Aybek S, Gronchi-Perrin A, Berney A, et al. Long-term cognitive profile and incidence of dementia after STN-DBS in Parkinson’s disease. Mov Disord. 05. 15. 2007;22(7):974-81. X-1, X-2, X-3, X-4. [pmid: 17443691].
156 Aybek S, Lazeyras F, Gronchi-Perrin A, et al. Hippocampal atrophy predicts conversion to dementia after STN-DBS in Parkinson’s disease. Parkinsonism Relat Disord. 08. 2009;15(7):521-4. X-1, X-3, X-4. [pmid: 19349206].
157 Aylott J. Developments in learning disability nursing over the last 10 years. Br J Nurs. 04. 11–24. 2002;11(7):498-500. X-1, X-2, X-3, X-4. [pmid: 11984465].
158 Ayres AJ, Mailloux ZK. Possible pubertal effect on therapeutic gains in an autistic girl. American Journal of Occupational Therapy. 08. 1983;37(8):535-540. X-3, X-10. [pmid: 6624850].
159 Ayres AJ, Tickle LS. Hyper-responsivity to touch and vestibular stimuli as a predictor of positive response to sensory integration procedures by autistic children. Am J Occup Ther. 06. 1980;34(6):375-81. X-10. [pmid: 6971048].
160 Ayres KM, Langone J. Intervention and Instruction with Video for Students with Autism: A Review of the Literature. Education and Training in Developmental Disabilities. 06. 2005;40(2):183-196. X-1, X-2, X-3, X-4.
161 Azadi B, Seddigh A, Tehrani-Doost M, et al. Executive dysfunction in treated phenylketonuric patients. Eur Child Adolesc Psychiatry. 06. 2009;18(6):360-8. X-1, X-4. [pmid: 19221856].
162 Azrin NH, Besalel VA, Jamner JP, et al. Comparative study of behavioral methods of treating severe self-injury. Behavioral Residential Treatment. 04. 1988;3(2):119-152. X-1, X-3, X-10.
163 Azrin NH, Vinas V, Ehle CT. Physical Activity as Reinforcement for Classroom Calmness of ADHD Children: A Preliminary Study. Child & Family Behavior Therapy. 06. 2007;29(2):1-8. X-1, X-3, X-4.
164 Ballte S, Bosch G. The Long-Term Outcome in Two Females with Autism Spectrum Disorder. Psychopathology. 05–06. 2005;38(3):151-154. X-1, X-3, X-4. [pmid: 15905639].
165 Ballte S, Hubl D, Feineis-Matthews S, et al. Facial affect recognition training in autism: Can we animate the fusiform gyrus?. Behavioral Neuroscience. 02. 2006;120(1):211-216. X-1, X-3, X-4. [pmid: 16492133].
166 Baas K. Specialty: autism approaches need to be tailored to each person. Pa Nurse. 03. 2006;61(1):14-5. X-1, X-2, X-3, X-4.
167 Babel DA, Martin GL, Fazzio D, et al. Assessment of the Reliability and Validity of the Discrete-Trials Teaching Evaluation Form. Developmental Disabilities Bulletin. 2008;36(1–2):67-80. X-1, X-4.
168 Baerg KL. Effective communication with autistic children. Rehabil Nurs. 03–04. 1991;16(2):8-90. discussion 90–3. X-1, X-2, X-3, X-4, X-10. [pmid: 2000468].
169 Baghdadli A, Pascal C, Grisi S, et al. Risk factors for self-injurious behaviours among 222 young children with autistic disorders. J Intellect Disabil Res. 11. 2003;47(Pt 8):622-7. X-4. [pmid: 14641810].
170 Baharav E, Darling R. Case Report: Using an Auditory Trainer with Caregiver Video Modeling to Enhance Communication and Socialization Behaviors in Autism. Journal of Autism and Developmental Disorders. 04. 2008;38(4):771-775. X-3. [pmid: 17710521].
171 Bailey SL, Pokrzywinski J, Bryant LE. Using water mist to reduce self-injurious and stereotypic behavior. Applied Research in Mental Retardation. 1983;4(3):229-241. X-10. [pmid: 6660866].
172 Bailine SH, Petraviciute S. Catatonia in autistic twins: role of electroconvulsive therapy. J ECT. 03. 2007;23(1):21-2. X-1, X-3, X-4. [pmid: 17435568].
173 Bain SK, Brown KS, Jordan KR. Teacher Candidates’ Accuracy of Beliefs regarding Childhood Interventions. Teacher Educator. 04. 2009;44(2):71-89. X-1, X-4.
174 Bainbridge N, Myles BS. The use of priming to introduce toilet training to a child with autism. Focus on Autism and Other Developmental Disabilities. Sum. 1999;14(2):106-109. X-10.
175 Baird G, Charman T, Baron-Cohen S, et al. A screening instrument for autism at 18 months of age: a 6-year follow-up study. J Am Acad Child Adolesc Psychiatry. 06. 2000;39(6):694-702. X-4. [pmid: 10846303].
176 Baird G, Pickles A, Simonoff E, et al. Measles vaccination and antibody response in autism spectrum disorders. Arch Dis Child. 10. 2008;93(10):832-7. X-4. [pmid: 18252754].
177 Bakare MO, Agomoh AO, Ebigbo PO, et al. Etiological explanation, treatability and preventability of childhood autism: A survey of Nigerian healthcare workers’ opinion. Annals of General Psychiatry. 2009;8(6). X-1, X-4.
178 Bakare MO, Ebigbo PO, Agomoh AO, et al. Knowledge about childhood autism and opinion among healthcare workers on availability of facilities and law caring for the needs and rights of children with childhood autism and other developmental disorders in Nigeria. BMC Pediatr. 2009;9:12. X-1, X-3, X-4. [pmid: 19216754].
179 Baker DL. Public Policy and the Shaping of Disability: Incidence Growth in Educational Autism. Education Policy Analysis Archives. 2004;12(11). 03. X-1, X-2, X-3, X-4.
180 Baker DL, Stokes S. Brain politics: Aspects of administration in the comparative issue definition of autism-related policy. Public Administration Review. 07. 2007;67(4):757-767. X-1, X-2, X-3, X-4.
181 Baker LJ, Milner Y. Sensory reinforcement with autistic children. Behavioural Psychotherapy. 10. 1985;13(4):328-341. X-3, X-10.
182 Baker MJ. Incorporating the thematic ritualistic behaviors of children with autism into games: Increasing social play interactions with siblings. Journal of Positive Behavior Interventions. Spr. 2000;2(2):66-84. X-3.
183 Baker MJ, Koegel RL, Koegel LK. Increasing the social behavior of young children with autism using their obsessive behaviors. Journal of the Association for Persons with Severe Handicaps. Win. 1998;23(4):300-308. X-10.
184 Baker SD, Lang R, O’Reilly M. Review of Video Modeling with Students with Emotional and Behavioral Disorders. Education and Treatment of Children. 08. 2009;32(3):403-420. X-1, X-2, X-3, X-4.
185 Baker SM. Sidney MacDonald Baker, MD: taking a biomedical approach to autism treatment. Interview by Frank Lampe and Suzanne Snyder. Altern Ther Health Med. 11–12. 2008;14(6):60-9. X-1, X-2, X-3, X-4.
186 Baker-Ericzen MJ, Brookman-Frazee L, Stahmer A. Stress Levels and Adaptability in Parents of Toddlers with and without Autism Spectrum Disorders. Research and Practice for Persons with Severe Disabilities (RPSD). Win. 2005;30(4):194-204. X-1, X-3, X-4.
187 Bala J. “Mama stop doing MMMMMMM”: TA in the treatment of autistic children. Transactional Analysis Journal. 10. 1986;16(4):234-239. X-1, X-2, X-3, X-4, X-10.
188 Ballaban-Gil K, Rapin I, Tuchman R, et al. Longitudinal examination of the behavioral, language, and social changes in a population of adolescents and young adults with autistic disorder. Pediatr Neurol. 10. 1996;15(3):217-23. X-3, X-4, X-10. [pmid: 8916159].
189 Banda DR, Grimmett E. Enhancing Social and Transition Behaviors of Persons with Autism through Activity Schedules: A Review. Education and Training in Developmental Disabilities. 09. 2008;43(3):324-333. X-1, X-2, X-3, X-4.
190 Banda DR, Grimmett E, Hart SL. Activity Schedules: Helping Students with Autism Spectrum Disorders in General Education Classrooms Manage Transition Issues. TEACHING Exceptional Children. 03–04. 2009;41(4):16-21. X-1, X-2, X-3, X-4.
191 Banda DR, Kubina RM Jr. The Effects of a High-Probability Request Sequencing Technique in Enhancing Transition Behaviors. Education & Treatment of Children. 08. 2006;29(3):507-516. X-1, X-3.
192 Banda DR, Kubina RM Jr. Increasing Academic Compliance with Mathematics Tasks Using the High-Preference Strategy with a Student with Autism. Preventing School Failure. 2010;54(2):81-85. X-1, X-3.
193 Banda DR, McAfee JK, Hart SL. Decreasing Self-Injurious Behavior in a Student with Autism and Tourette Syndrome through Positive Attention and Extinction. Child & Family Behavior Therapy. 2009;31(2):144-156. X-3.
194 Banjade DP, Shrestha SL, Shukri A, et al. A simplified approach for exit dose in vivo measurements in radiotherapy and its clinical application. Australas Phys Eng Sci Med. 09. 2002;25(3):110-8. X-1, X-3, X-4. [pmid: 12416587].
195 Bara BG, Bucciarelli M, Colle L. Communicative abilities in autism: evidence for attentional deficits. Brain Lang. 05. 2001;77(2):216-40. X-1, X-4. [pmid: 11300705].
196 Barakova E, Gillessen J, Feijs L. Social training of autistic children with interactive intelligent agents. J Integr Neurosci. 03. 2009;8(1):23-34. X-6. [pmid: 19412978].
197 Baranek GT. Efficacy of sensory and motor interventions for children with autism. J Autism Dev Disord. 10. 2002;32(5):397-422. X-1, X-2, X-3, X-4. [pmid: 12463517].
198 Baranek GT, Boyd BA, Poe MD, et al. Hyperresponsive sensory patterns in young children with autism, developmental delay, and typical development. American Journal on Mental Retardation. 07. 2007;112(4):233-245. X-4. [pmid: 17559291].
199 Baranek GT, Foster LG, Berkson G. Tactile defensiveness and stereotyped behaviors. Am J Occup Ther. 02. 1997;51(2):91-5. X-4, X-10. [pmid: 9124275].
200 Barbera ML, Kubina RM Jr. Using Transfer Procedures to Teach Tacts to a Child with Autism, Analysis of Verbal Behavior Journal Citation. 2005;21:155-161. Publisher: Association for Behavior Analysis International. 1219 South Park Street, Kalamazoo, MI 49001. Tel: 269-492-9310; Fax: 269-492-9316. e-mail: mail@abainternational.org; Web site: http://www.abainternational.org/TAVB.asp. 2005 Pub Types: Journal Articles; Reports - Research. X-3.
201 Bardenheier B, Yusuf H, Schwartz B, et al. Are parental vaccine safety concerns associated with receipt of measles-mumps-rubella, diphtheria and tetanus toxoids with acellular pertussis, or hepatitis B vaccines by children?. Arch Pediatr Adolesc Med. 06. 2004;158(6):569-75. X-1, X-4. [pmid: 15184221].
202 Barnard L, Young AH, Pearson J, et al. A systematic review of the use of atypical antipsychotics in autism. J Psychopharmacol. 03. 2002;16(1):93-101. X-1, X-2, X-3, X-4. [pmid: 11949778].
203 Barnhill GP, Cook KT, Tebbenkamp K, et al. The Effectiveness of Social Skills Intervention Targeting Nonverbal Communication for Adolescents with Asperger Syndrome and Related Pervasive Developmental Delays. Focus on Autism and Other Developmental Disabilities. 2002. X-1, X-3.
204 Baron-Cohen S, Scott FJ, Allison C, et al. Prevalence of autism-spectrum conditions: UK school-based population studies. British Journal of Psychiatry. 06. 2009;194(6):500-509. X-1, X-4. [pmid: 19478287].
205 Barone P, Burn DJ, van Laar T, et al. Rivastigmine versus placebo in hyperhomocysteinemic Parkinson’s disease dementia patients. Mov Disord. 08. 15. 2008;23(11):1532-40. X-1, X-2, X-3, X-4. [pmid: 18581467].
206 Barrera RD, Lobato-Barrera D, Sulzer-Azaroff B. A simultaneous treatment comparison of three expressive language training programs with a mute autistic child. Journal of Autism and Developmental Disorders. 03. 1980;10(1):21-37. X-10. [pmid: 6927676].
207 Barrera RD, Sulzer-Azaroff B. An alternating treatment comparison of oral and total communications training programs with echolalic autistic children. J Appl Behav Anal. Winter. 1983;16(4):379-94. X-10. [pmid: 6654770].
208 Barrett P, Healy-Farrell L, March JS. Cognitive-behavioral family treatment of childhood obsessive-compulsive disorder: a controlled trial. J Am Acad Child Adolesc Psychiatry. 01. 2004;43(1):46-62. X-2, X-4. [pmid: 14691360].
209 Barrett PM, Duffy AL, Dadds MR, et al. Cognitive-behavioral treatment of anxiety disorders in children: long-term (6-year) follow-up. J Consult Clin Psychol. 02. 2001;69(1):135-41. X-1, X-4. [pmid: 11302272].
210 Barrett RP, Feinstein C, Hole WT. Effects of naloxone and naltrexone on self-injury: A double-blind, placebo-controlled analysis. American Journal on Mental Retardation. Special Issue: Drug treatment. 05. 1989;93(6):644-651. X-3, X-10.
211 Barrows P. The use of stories as autistic objects. Journal of Child Psychotherapy. 04. 2001;27(1):69-82. X-2, X-3, X-4.
212 Barrows P. Becoming verbal: Autism, trauma and playfulness. Journal of Child Psychotherapy. 04. 2002;28(1):53-72. X-3.
213 Barry LM, Burlew SB. Using Social Stories to Teach Choice and Play Skills to Children with Autism. Focus on Autism and Other Developmental Disabilities. 03. 2004;19(1):45-51. X-3.
214 Barry LM, Singer GHS. A family in crisis: Replacing the aggressive behavior of a child with autism toward an infant sibling. Journal of Positive Behavior Interventions. Win. 2001;3(1):28-38. X-3.
215 Barry TD, Klinger LG, Lee JM, et al. Examining the effectiveness of an outpatient clinic-based social skills group for high-functioning children with autism. J Autism Dev Disord. 12. 2003;33(6):685-701. X-3. [pmid: 14714936].
216 Barthelemy C, Bruneau N, Jouve J, et al. Urinary dopamine metabolites as indicators of the responsiveness to fenfluramine treatment in children with autistic behavior. J Autism Dev Disord. 06. 1989;19(2):241-54. X-4, X-10. [pmid: 2745390].
217 Bartley JJ. An update on autism: science, gender, and the law. Gend Med. 06. 2006;3(2):73-8. X-1, X-2, X-3, X-4. [pmid: 16860267].
218 Bartman S, Freeman N. Teaching language to a two-year-old with autism. Journal on Developmental Disabilities. Fal. 2003;10(1):47-53. X-3.
219 Bartrum T, Bailey M, Nelson V, et al. Linear attenuation coefficients for compensator based IMRT. Australas Phys Eng Sci Med. 12. 2007;30(4):281-7. X-1, X-2, X-3, X-4. [pmid: 18274068].
220 Bass JD, Mulick JA. Social Play Skill Enhancement of Children with Autism Using Peers and Siblings as Therapists. Psychology in the Schools. 09. 2007;44(7):727-735. X-1, X-2, X-3, X-4.
221 Bassoukou IH, Nicolau J, dos Santos MT. Saliva flow rate, buffer capacity, and pH of autistic individuals. Clin Oral Investig. 03. 2009;13(1):23-7. X-4.
222 Bateman DF. Due Process Hearing Case Study. TEACHING Exceptional Children. 03–04. 2009;41(4):73-75. X-2, X-4.
223 Bauer W, Bauer JL. Adolescent schizophrenia. Adolescence. Fall. 1982;17(67):685-93. X-1, X-2, X-3, X-4, X-10. [pmid: 7180632].
224 Bauminger N. The facilitation of social-emotional understanding and social interaction in high-functioning children with autism: intervention outcomes. J Autism Dev Disord. 08. 2002;32(4):283-98. X-1. [pmid: 12199133].
225 Beadle-Brown J, Murphy G, Wing L, et al. Changes in skills for people with intellectual disability: a follow-up of the Camberwell Cohort. J Intellect Disabil Res. 02. 2000;44(Pt 1):12-24. X-1, X-4. [pmid: 10711646].
226 Beall PM, Moody EJ, McIntosh DN, et al. Rapid facial reactions to emotional facial expressions in typically developing children and children with autism spectrum disorder. Journal of Experimental Child Psychology. 11. 2008;101(3):206-223. X-4. [pmid: 18561942].
227 Beard-Pfeuffer M. Understanding the world of children with autism. RN. 02. 2008;71(2):40-5. quiz 46. X-1, X-2, X-3, X-4. [pmid: 18386443].
228 Beatson JE. Walk a mile in their shoes: Implementing family-centered care in serving children and families affected by autism spectrum disorder. Topics in Language Disorders. 10–12. 2008;28(4):309-322. X-1, X-4.
229 Beaver DL, Hayes PL, Luetke-Stahlman B. In-service trends. General education teachers working with educational interpreters. Am Ann Deaf. 03. 1995;140(1):38-46. X-1, X-4, X-10. [pmid: 7778516].
230 Bebbington A, Beecham J. Social services support and expenditure for children with autism. Autism. 01. 2007;11(1):43-61. X-4. [pmid: 17175573].
231 Bebko JM, Konstantareas MM, Springer J. Parent and professional evaluations of family stress associated with characteristics of autism. J Autism Dev Disord. 12. 1987;17(4):565-76. X-1, X-4, X-10. [pmid: 3680156].
232 Bebko JM, Lennox C. Teaching the control of diurnal bruxism to two children with autism using a simple cueing procedure. Behavior Therapy. Spr. 1988;19(2):249-255. X-3, X-10.
233 Bebko JM, Perry A, Bryson S. Multiple method validation study of facilitated communication: II. Individual differences and subgroup results. J Autism Dev Disord. 02. 1996;26(1):19-42. X-10. [pmid: 8819769].
234 Beck AR, Pirovano CM. Facilitated communicators’ performance on a task of receptive language. J Autism Dev Disord. 10. 1996;26(5):497-512. X-10. [pmid: 8906452].
235 Beck MH, Cataldo M, Slifer KJ, et al. Teaching Children with Attention Deficit Hyperactivity Disorder (ADHD) and Autistic Disorder (AD) How to Swallow Pills. Clinical Pediatrics. 07–08. 2005;44(6):515-526. X-3. [pmid: 16015399].
236 Becker KG. Autism, asthma, inflammation, and the hygiene hypothesis. Med Hypotheses. 2007;69(4):731-40. X-2. [pmid: 17412520].
237 Becker-Cottrill B, McFarland J, Anderson V. A model of positive behavioral support for individuals with autism and their families: The family focus process. Focus on Autism and Other Developmental Disabilities. Sum. 2003;18(2):113-123. X-3.
238 Bedford JL, Hansen VN, Webb S. The derivation of tissue-maximum ratio from percentage depth dose requires peak scatter factor to be considered a function of source-to-surface distance. Br J Radiol. 08. 1998;71(848):876-81. X-10. [pmid: 9828802].
239 Beeghly JH, Kuperman S, Perry PJ, et al. Fenfluramine treatment of autism: relationship of treatment response to blood levels of fenfluramine and norfenfluramine. J Autism Dev Disord. 12. 1987;17(4):541-8. X-3, X-4, X-10. [pmid: 3316172].
240 Beisler JM, Tsai LY. A pragmatic approach to increase expressive language skills in young autistic children. J Autism Dev Disord. 09. 1983;13(3):287-303. X-3, X-10. [pmid: 6643374].
241 Beisler JM, Tsai LY, Stiefel B. The effects of fenfluramine on communication skills in autistic children. J Autism Dev Disord. 06. 1986;16(2):227-33. X-3, X-10. [pmid: 3722120].
242 Beitchman JH. Childhood schizophrenia. A review and comparison with adult-onset schizophrenia. Psychiatr Clin North Am. 12. 1985;8(4):793-814. X-1, X-2, X-3, X-4, X-10. [pmid: 3878510].
243 Belcher TL. Behavioral treatment vs behavioral control: A case study. Journal of Developmental and Physical Disabilities. 09. 1995;7(3):235-241. X-1, X-3, X-10.
244 Belfiore PJ, Fritts KM, Herman BC. The Role of Procedural Integrity: Using Self-Monitoring to Enhance Discrete Trial Instruction (DTI). Focus on Autism and Other Developmental Disabilities. 06. 2008;23(2):95-102. X-1, X-3, X-4.
245 Bell JG, MacKinlay EE, Dick JR, et al. Essential fatty acids and phospholipase A2 in autistic spectrum disorders. Prostaglandins Leukot Essent Fatty Acids. 10. 2004;71(4):201-4. X-4. [pmid: 15301788].
246 Bell KS, Kirby JR. Teaching emotion and belief as mindreading instruction for children with autism. Developmental Disabilities Bulletin. 2002;30(1):16-50. X-3.
247 Bell MD, Conway Greig T, Bryson G, et al. Patterns of object relations and reality testing deficits in schizophrenia: clusters and their symptom and personality correlates. J Clin Psychol. 12. 2001;57(12):1353-67. X-1, X-4. [pmid: 11745581].
248 Bellini S, Akullian J, Hopf A. Increasing social engagement in young children with autism spectrum disorders using video self-modeling. School Psychology Review. 2007;36(1):80-90. X-3.
249 Bellini S, Hopf A. The Development of the “Autism Social Skills Profile”: A Preliminary Analysis of Psychometric Properties. Focus on Autism and Other Developmental Disabilities. Sum. 2007;22(2):80-87. X-4.
250 Bellini S, Peters JK, Benner L, et al. A Meta-Analysis of School-Based Social Skills Interventions for Children With Autism Spectrum Disorders. Remedial and Special Education. 05–06. 2007;28(3):153-162. X-1, X-2, X-3.
251 Bellon ML, Ogletree BT, Harn WE. Repeated storybook reading as a language intervention for children with autism: A case study on the application of scaffolding. Focus on Autism and Other Developmental Disabilities. Spr. 2000;15(1):52-58. X-3.
252 Bellon-Harn ML, Harn WE. Scaffolding Strategies during Repeated Storybook Reading: An Extension Using a Voice Output Communication Aid. Focus on Autism and Other Developmental Disabilities. 2008;23(2):112-124. X-3, X-4.
253 Bellon-Harn ML, Harn WE, Watson GD. Targeting Prosody in an Eight-Year-Old Child with High-Functioning Autism during an Interactive Approach to Therapy. Child Language Teaching and Therapy. 2007;23(2):157-179. X-3.
254 Belsito KM, Law PA, Kirk KS, et al. Lamotrigine therapy for autistic disorder: a randomized, double-blind, placebo-controlled trial. J Autism Dev Disord. 04. 2001;31(2):175-81. X-3. [pmid: 11450816].
255 Benedetti G. Interview with Gaetano Benedetti, M.D. J Am Acad Psychoanal Dyn Psychiatry. Spring. 2003;31(1):75-87. X-1, X-2, X-3, X-4. [pmid: 12722889].
256 Bennett S, McKenna K, Tooth L, et al. Searches and content of the OTseeker database: informing research priorities. Am J Occup Ther. 09–10. 2006;60(5):524-30. X-1, X-3, X-4. [pmid: 17022340].
257 Ben-Sasson A, Hen L, Fluss R, et al. A Meta-Analysis of Sensory Modulation Symptoms in Individuals with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 01. 2009;39(1):1-11. X-2, X-4. [pmid: 18512135].
258 Benson P, Karlof KL, Siperstein GN. Maternal involvement in the education of young children with autism spectrum disorders. Autism. 01. 2008;12(1):47-63. X-4. [pmid: 18178596].
259 Bentivegna S, Schwartz L, Deschner D. The use of art with an autistic child in residential care. Am J Art Ther. 01. 1983;22(2):51-6. X-10. [pmid: 10318567].
260 Benveniste D. The archetypal image of the mouth and its relation to autism. The Arts in Psychotherapy. Sum. 1983;10(2):99-112. X-3, X-4, X-10.
261 Berger HJ, van Spaendonck KP, Horstink MW, et al. Cognitive shifting as a predictor of progress in social understanding in high-functioning adolescents with autism: a prospective study. J Autism Dev Disord. 06. 1993;23(2):341-59. X-10. [pmid: 8331051].
262 Bergmann F, Stepp H, Metzger R, et al. In vitro and in vivo evaluation of photodynamic techniques for the experimental treatment of human hepatoblastoma and neuroblastoma: preliminary results. Pediatr Surg Int. 12. 2008;24(12):1331-3. X-4. [pmid: 19009300].
263 Berkowitz S. A comparison of two methods of prompting in training discrimination of communication book pictures by autistic students. J Autism Dev Disord. 06. 1990;20(2):255-62. X-3, X-10. [pmid: 2347823].
264 Berliner DL, Monti-Bloch L, Jennings-White C, et al. The functionality of the human vomeronasal organ (VNO): evidence for steroid receptors. J Steroid Biochem Mol Biol. 06. 1996;58(3):259-65. X-1, X-4, X-10. [pmid: 8836161].
265 Bernad-Ripoll S. Using a Self-as-Model Video Combined with Social Stories to Help a Child with Asperger Syndrome Understand Emotions. Focus on Autism and Other Developmental Disabilities. Sum. 2007;22(2):100-106. X-3.
266 Bernard-Opitz V, Ing S, Kong TY. Comparison of behavioural and natural play interventions for young children with autism. Autism. 09. 2004;8(3):319-33. X-3. [pmid: 15358873].
267 Bernard-Opitz V, Kok A. Training parents of autistic children in Singapore. Int J Rehabil Res. 1992;15(1):82-4. X-10. [pmid: 1601571].
268 Bernard-Opitz V, Kwook KW, Sapuan S. Epidemiology of autism in Singapore: findings of the first autism survey. Int J Rehabil Res. 03. 2001;24(1):1-6. X-1, X-4. [pmid: 11302459].
269 Bernard-Opitz V, Ross K, Tuttas ML. Computer assisted instruction for autistic children. Ann Acad Med Singapore. 09. 1990;19(5):611-6. X-10. [pmid: 2260815].
270 Bernard-Opitz V, Sriram N, Nakhoda-Sapuan S. Enhancing social problem solving in children with autism and normal children through computer-assisted instruction. J Autism Dev Disord. 08. 2001;31(4):377-84. X-3. [pmid: 11569584].
271 Bernard-Opitz V, Sriram N, Sapuan S. Enhancing vocal imitations in children with autism using the IBM SpechViewer. Autism. 06. 1999;3(2):131-147. X-10.
272 Bernstein H, Brown BL, Sturmey P. The Effects of Fixed Ratio Values on Concurrent Mand and Play Responses. Behavior Modification. 2009;33(2):199-206. X-3. [pmid: 18523130].
273 Bernstein H, Sturmey P. Effects of Fixed-Ratio Schedule Values on Concurrent Mands in Children with Autism. Research in Autism Spectrum Disorders. 04–06. 2008;2(2):362-370. X-3.
274 Berry-Kravis E, Krause SE, Block SS, et al. Effect of CX516, an AMPA-modulating compound, on cognition and behavior in fragile X syndrome: a controlled trial. J Child Adolesc Psychopharmacol. 10. 2006;16(5):525-40. X-1, X-4. [pmid: 17069542].
275 Berry-Kravis E, Sumis A, Kim O-K, et al. Characterization of Potential Outcome Measures for Future Clinical Trials in Fragile X Syndrome. Journal of Autism and Developmental Disorders. 10. 2008;38(9):1751-1757. X-1, X-4. [pmid: 18369716].
276 Bettison S. The long-term effects of auditory training on children with autism. J Autism Dev Disord. 06. 1996;26(3):361-74. X-10. [pmid: 8792266].
277 Betz A, Higbee TS, Reagon KA. Using joint activity schedules to promote peer engagement in preschoolers with autism. J Appl Behav Anal. Summer. 2008;41(2):237-41. X-3. [pmid: 18595287].
278 Beversdorf DQ, Carpenter AL, Miller RF, et al. Effect of propranolol on verbal problem solving in autism spectrum disorder. Neurocase. 2008;14(4):378-83. X-1, X-3, X-4. [pmid: 18766980].
279 Bhardwaj A, Agarwal V, Sitholey P. Asperger’s disorder with co-morbid separation anxiety disorder: a case report. J Autism Dev Disord. 02. 2005;35(1):135-6. X-3. [pmid: 15796129].
280 Bhaumik S, Branford D, McGrother C, et al. Autistic traits in adults with learning disabilities. Br J Psychiatry. 06. 1997;170:502-6. X-1, X-4, X-10. [pmid: 9330013].
281 Bhaumik S, Tyrer FC, McGrother C, et al. Psychiatric service use and psychiatric disorders in adults with intellectual disability. J Intellect Disabil Res. 11. 2008;52(11):986-95. X-1, X-4. [pmid: 19017168].
282 Bianco M, Carothers DE, Smiley LR. Gifted Students with Asperger Syndrome: Strategies for Strength-Based Programming. Intervention in School and Clinic. 2009;44(4):206-215. X-1, X-2, X-3, X-4.
283 Bierly C, Billingsley FF. An investigation of the educative effects of overcorrection on the behavior of an autistic child. Behavioral Disorders. 11. 1983;9(1):11-21. X-3, X-10.
284 Bigelow KM, Huynen KB, Lutzker JR. Using a changing criterion design to teach fire escape to a child with developmental disabilities. Journal of Developmental and Physical Disabilities. 06. 1993;5(2):121-128. X-3, X-10.
285 Billard A, Robins B, Nadel J, et al. Building Robota, a mini-humanoid robot for the rehabilitation of children with autism. Assist Technol. Spring. 2007;19(1):37-49. X-1, X-2, X-3, X-4. [pmid: 17461289].
286 Billstedt E, Gillberg C, Gillberg C. Autism after Adolescence: Population-Based 13- to 22-Year Follow-Up Study of 120 Individuals with Autism Diagnosed in Childhood. Journal of Autism and Developmental Disorders. 06. 2005;35(3):351-360. X-1, X-4. [pmid: 16119476].
287 Binnendyk L, Lucyshyn JM. A Family-Centered Positive Behavior Support Approach to the Amelioration of Food Refusal Behavior: An Empirical Case Study. Journal of Positive Behavior Interventions. 2009;11(1):47-62. X-3.
288 Bird F, Dores PA, Moniz D, et al. Reducing severe aggressive and self-injurious behaviors with functional communication training. American Journal on Mental Retardation. 07. 1989;94(1):37-48. X-1, X-3, X-10. [pmid: 2751890].
289 Bird G, Leighton J, Press C, et al. Intact automatic imitation of human and robot actions in autism spectrum disorders. Proc Biol Sci. 12. 7. 2007;274(1628):3027-31. X-1, X-4. [pmid: 17911053].
290 Birenbaum A, Cohen HJ. On the importance of helping families: policy implications from a national study. Ment Retard. 04. 1993;31(2):67-74. X-1, X-2, X-3, X-4, X-10. [pmid: 8479331].
291 Birkan B, McClannahan LE, Krantz PJ. Effects of Superimposition and Fading on the Sight-Word Reading of a Boy with Autism. Research in Autism Spectrum Disorders Journal Citation. 04–06. 2007;1(2):117-125. Publisher: Elsevier. 6277 Sea Harbor Drive, Orlando, FL 32887-4800. Tel: 877-839-7126; Tel: 407-345-4020; Fax: 407-363-1354; e-mail: usjcs@elsevier.com; Web site: http://www.elsevier.com. 2007 Pub Types: Journal Articles; Reports - Research. X-3.
292 Birkin C, Anderson A, Moore DW, et al. Evaluating the Efficacy of Parent-Focused Interventions for Autism: How Do We Know What Will Work?. Australian Journal of Early Childhood. 09. 2004;29(3):42-47. X-1.
293 Birkin C, Anderson A, Seymour F, et al. A parent-focused early intervention program for autism: who gets access?. J Intellect Dev Disabil. 06. 2008;33(2):108-16. X-1, X-3, X-4. [pmid: 18569398].
294 Birmaher B, Quintana H, Greenhill LL. Methylphenidate treatment of hyperactive autistic children. J Am Acad Child Adolesc Psychiatry. 03. 1988;27(2):248-51. X-10. [pmid: 3360732].
295 Birnbrauer JS, Leach DJ. The Murdoch Early Intervention Program after 2 years. Behaviour Change. 1993;10(2):63-74. X-10.
296 Bisagni F. The Sound-Hand. Journal of Child Psychotherapy. 12. 2009;35(3):229-249. X-2, X-3, X-4.
297 Bishop DV. Curing dyslexia and attention-deficit hyperactivity disorder by training motor co-ordination: miracle or myth?. J Paediatr Child Health. 10. 2007;43(10):653-5. X-1, X-2, X-3, X-4. [pmid: 17854448].
298 Bishop SL, Richler J, Cain AC, et al. Predictors of Perceived Negative Impact in Mothers of Children With Autism Spectrum Disorder. American Journal on Mental Retardation. 11. 2007;112(6):450-461. X-1, X-4. [pmid: 17963436].
299 Bishop SL, Richler J, Lord C. Association between restricted and repetitive behaviors and nonverbal IQ in children with autism spectrum disorders. Child Neuropsychol. 08. 2006;12(4–5):247-67. X-4. [pmid: 16911971].
300 Bitsika V, Sharpley C. An explanatory examination of the effects of support groups on the well-being of parents of children with autism: I: General counselling. Journal of Applied Health Behaviour. 1999;1(2):16-22. X-1, X-4, X-10.
301 Bitsika V, Sharpley C. Development and testing of the effects of support groups on the well-being of parents of children with autism-II: Specific stress management techniques. Journal of Applied Health Behaviour. 2000;2(1):8-15. X-1, X-4.
302 Bitsika V, Sharpley CF, Orapeleng S. An Exploratory Analysis of the Use of Cognitive, Adaptive and Behavioural Indices for Cluster Analysis of ASD Subgroups. Journal of Intellectual Disability Research. 11. 2008;52(11):973-985. X-4. [pmid: 19017167].
303 Bitterman A, Daley TC, Misra S, et al. A national sample of preschoolers with autism spectrum disorders: special education services and parent satisfaction. J Autism Dev Disord. 09. 2008;38(8):1509-17. X-4. [pmid: 18228122].
304 Blacher J, McIntyre LL. Syndrome specificity and behavioural disorders in young adults with intellectual disability: cultural differences in family impact. J Intellect Disabil Res. 03. 2006;50(Pt 3):184-98. X-4. [pmid: 16430730].
305 Blackledge JT, Hayes SC. Using Acceptance and Commitment Training in the Support of Parents of Children Diagnosed with Autism. Child & Family Behavior Therapy. 2006;28(1):1-18. X-1.
306 Blackwood DH, Muir WJ, Roxborough HM, et al. “Schizoid” personality in childhood: auditory P300 and eye tracking responses at follow-up in adult life. J Autism Dev Disord. 08. 1994;24(4):487-500. X-1, X-4, X-10. [pmid: 7961332].
307 Blair J, Scahill L, State M, et al. Electrocardiographic changes in children and adolescents treated with ziprasidone: a prospective study. J Am Acad Child Adolesc Psychiatry. 01. 2005;44(1):73-9. X-1, X-4. [pmid: 15608546].
308 Blair K-SC, Umbreit J, Dunlap G, et al. Promoting Inclusion and Peer Participation through Assessment-Based Intervention. Topics in Early Childhood Special Education. Fall. 2007;27(3):134-147. X-3.
309 Blairs S, Slater S, Hare DJ. The Clinical Application of Deep Touch Pressure with a Man with Autism Presenting with Severe Anxiety and Challenging Behaviour. British Journal of Learning Disabilities. 12. 2007;35(4):214-220. X-1, X-3.
310 Blakeley-Smith A, Carr EG, Cale SI, et al. Environmental Fit: A Model for Assessing and Treating Problem Behavior Associated with Curricular Difficulties in Children with Autism Spectrum Disorders. Focus on Autism and Other Developmental Disabilities. 2009;24(3):131-145. X-3.
311 Bledsoe R, Myles BS, Simpson R. Use of a Social Story intervention to improve mealtime skills of an adolescent with Asperger syndrome. Autism. 09. 2003;7(3):289-295. X-3. [pmid: 14516061].
312 Blindert HD, Hartridge CL, Gwadry FG. Controlling self-injurious escape behaviors. Behavioral Interventions. 07. 1995;10(3):173-179. X-3, X-10.
313 Bloch J, Gersten E, Kornblum S. Evaluation of a language program for young autistic children. J Speech Hear Disord. 02. 1980;45(1):76-89. X-10. [pmid: 7354632].
314 Bock MA. Acquisition, maintenance, and generalization of a categorization strategy by children with autism. Journal of Autism and Developmental Disorders. 02. 1994;24(1):39-51. X-10. [pmid: 8188573].
315 Bock MA. The Impact of Social-Behavioral Learning Strategy Training on the Social Interaction Skills of Four Students with Asperger Syndrome. Focus on Autism and Other Developmental Disabilities. Sum. 2007;22(2):88-95. X-3.
316 Bock MA. A Social-Behavioral Learning Strategy Intervention for a Child with Asperger Syndrome: Brief Report. Remedial and Special Education. 09–10. 2007;28(5):258-265. X-3.
317 Boddaert N, Belin P, Chabane N, et al. Perception of complex sounds: abnormal pattern of cortical activation in autism. Am J Psychiatry. 11. 2003;160(11):2057-60. X-1, X-3, X-4. [pmid: 14594758].
318 Boddaert N, Chabane N, Belin P, et al. Perception of complex sounds in autism: abnormal auditory cortical processing in children. Am J Psychiatry. 11. 2004;161(11):2117-20. X-4. [pmid: 15514415].
319 Boddy F, Rowan EN, Lett D, et al. Subjectively reported sleep quality and excessive daytime somnolence in Parkinson’s disease with and without dementia, dementia with Lewy bodies and Alzheimer’s disease. Int J Geriatr Psychiatry. 06. 2007;22(6):529-35. X-1, X-4. [pmid: 17096456].
320 Boettcher M, Koegel RL, McNerney EK, et al. A family-centered prevention approach to PBS in a time of crisis. Journal of Positive Behavior Interventions. Win. 2003;5(1):55-59. X-3.
321 Bogte H, Flamma B, van der Meere J. Do high functioning autistic individuals treated in a residential setting differ in divided attention abilities from those treated in an out-patient setting?. Int J Circumpolar Health. 2002;61(Suppl 2):15-21. X-1, X-4. [pmid: 12585817].
322 Bogte H, Flamma B, Van Der Meere J, et al. Divided Attention Capacity in Adults with Autism Spectrum Disorders and without Intellectual Disability. Autism: The International Journal of Research and Practice. 2009;13(3):229-243. X-4. [pmid: 19369386].
323 Boiron M, Barthelemy C, Adrien JL, et al. The assessment of psychophysiological dysfunction in children using the BSE scale before and during therapy. Acta Paedopsychiatr. 1992;55(4):203-6. X-10. [pmid: 1492548].
324 Bokszanska A, Martin G, Vanstraelen M, et al. Risperidone and olanzapine in adults with intellectual disability: a clinical naturalistic study. Int Clin Psychopharmacol. 09. 2003;18(5):285-91. X-1, X-3, X-4. [pmid: 12920389].
325 Bolman WM. Brief Report: 25-Year Follow-Up of a High-Functioning Autistic Child. Journal of Autism and Developmental Disorders. 01. 2008;38(1):181-183. X-1, X-3, X-4. [pmid: 17364231].
326 Bolman WM, Richmond JA. A double-blind, placebo-controlled, crossover pilot trial of low dose dimethylglycine in patients with autistic disorder. J Autism Dev Disord. 06. 1999;29(3):191-4. X-1, X-3, X-10. [pmid: 10425581].
327 Bolte S, Feineis-Matthews S, Leber S, et al. The development and evaluation of a computer-based program to test and to teach the recognition of facial affect. Int J Circumpolar Health. 2002;61(Suppl 2):61-8. X-1, X-3.
328 Bolton J, Mayer MD. Promoting the Generalization of Paraprofessional Discrete Trial Teaching Skills. Focus on Autism and Other Developmental Disabilities. 2008;23(2):103-111. X-1, X-3, X-4.
329 Bomba C, O’Donnell L, Markowitz C, et al. Evaluating the impact of facilitated communication on the communicative competence of fourteen students with autism. J Autism Dev Disord. 02. 1996;26(1):43-58. X-10. [pmid: 8819770].
330 Bonde E. Comorbidity and subgroups in childhood autism. Eur Child Adolesc Psychiatry. 03. 2000;9(1):7-10. X-4. [pmid: 10795850].
331 Bondy AS, Frost LA. The Picture Exchange Communication System. Focus on Autistic Behavior. 08. 1994;9(3):1-19. X-10.
332 Bonelli SB, Ransmayr G, Steffelbauer M, et al. L-dopa responsiveness in dementia with Lewy bodies, Parkinson disease with and without dementia. Neurology. 07. 27. 2004;63(2):376-8. X-1, X-4. [pmid: 15277644].
333 Bono MA, Daley T, Sigman M. Relations among Joint Attention, Amount of Intervention and Language Gain in Autism. Journal of Autism and Developmental Disorders. 10. 2004;34(5):495-505. X-4. [pmid: 15628604].
334 Bonta JL, Watters RG. Use of manual signs by developmentally disordered speech-deficient children in delayed auditory-to-picture matching-to-sample. Analysis & Intervention in Developmental Disabilities. 1983;3(4):295-309. X-10.
335 Bonvillian JD, Nelson KE, Rhyne JM. Sign language and autism. J Autism Dev Disord. 03. 1981;11(1):125-37. X-10. [pmid: 6927693].
336 Boon-Yasidhi V, Tarugsa J, Suwanwattana C, et al. Risperidone in the treatment of autistic Thai children under 4 years of age. J Med Assoc Thai. 08. 2002;85(Suppl 2):S784-9. X-3. [pmid: 12403261].
337 Bopp KD, Mirenda P, Zumbo BD. Behavior Predictors of Language Development over 2 Years in Children with Autism Spectrum Disorders. Journal of Speech, Language, and Hearing Research. 10. 2009;52(5):1106-1120. X-4.
338 Boris M, Kaiser CC, Goldblatt A, et al. Effect of pioglitazone treatment on behavioral symptoms in autistic children. J Neuroinflammation. 2007;4:3. X-3. [pmid: 17207275].
339 Borrero CS, Borrero JC. Descriptive and experimental analyses of potential precursors to problem behavior. J Appl Behav Anal. Spring. 2008;41(1):83-96. X-3, X-4. [pmid: 18468281].
340 Bosboom JL, Stoffers D, Stam CJ, et al. Cholinergic modulation of MEG resting-state oscillatory activity in Parkinson’s disease related dementia. Clin Neurophysiol. 05. 2009;120(5):910-5. X-1, X-3, X-4. [pmid: 19386543].
341 Boso M, Emanuele E, Minazzi V, et al. Effect of long-term interactive music therapy on behavior profile and musical skills in young adults with severe autism. J Altern Complement Med. 09. 2007;13(7):709-12. X-1, X-3. [pmid: 17931062].
342 Bosseler A, Massaro DW. Development and evaluation of a computer-animated tutor for vocabulary and language learning in children with autism. J Autism Dev Disord. 12. 2003;33(6):653-72. X-3. [pmid: 14714934].
343 Botts BH, Hershfeldt PA, Christensen-Sandfort RJ. Snoezelen[R]: Empirical Review of Product Representation. Focus on Autism and Other Developmental Disabilities. 2008;23(3):138-147. X-1, X-2, X-3, X-4.
344 Boucher J, Bigham S, Mayes A, et al. Recognition and language in low functioning autism. J Autism Dev Disord. 08. 2008;38(7):1259-69. X-4. [pmid: 18064549].
345 Bouder JN, Spielman S, Mandell DS. Brief report: Quantifying the impact of autism coverage on private insurance premiums. J Autism Dev Disord. 06. 2009;39(6):953-7. X-1, X-2, X-3, X-4. [pmid: 19214727].
346 Boulton TJ, Smith R, Single T. Psychosocial growth failure: a positive response to growth hormone and placebo. Acta Paediatr. 04. 1992;81(4):322-5. X-1, X-3, X-4, X-10. [pmid: 1606393].
347 Boulware G-L, Schwartz IS, Sandall SR, et al. Project DATA for Toddlers: An Inclusive Approach to Very Young Children with Autism Spectrum Disorder. Topics in Early Childhood Special Education. Sum. 2006;26(2):94-105. X-3.
348 Bouma R, Schweitzer R. The impact of chronic childhood illness on family stress: a comparison between autism and cystic fibrosis. J Clin Psychol. 11. 1990;46(6):722-30. X-1, X-4, X-10. [pmid: 2286663].
349 Bourret J, Vollmer TR, Rapp JT. Evaluation of a Vocal Mand Assessment and Vocal Mand Training Procedures, Journal of Applied Behavior Analysis Journal Citation. Sum. 2004;37(2):129. Publisher: Department of Applied Behavioral Science. 1000 Sunnyside Ave., KU, Lawrence, KS 66045-2133. Web site: http://seab.envmed.rochester.edu. 2004 06–22 Pub Types: Journal Articles. X-3.
350 Bouvard MP, Leboyer M, Launay JM, et al. Low-dose naltrexone effects on plasma chemistries and clinical symptoms in autism: a double-blind, placebo-controlled study. Psychiatry Res. 10. 16. 1995;58(3):191-201. X-10. [pmid: 8570775].
351 Bowers L. An audit of referrals of children with autistic spectrum disorder to the dietetic service. J Hum Nutr Diet. 04. 2002;15(2):141-4. X-1, X-3, X-4. [pmid: 11972743].
352 Bowler DM, Briskman JA. Photographic cues do not always facilitate performance on false belief tasks in children with autism. Journal of Autism and Developmental Disorders. 08. 2000;30(4):305-316. X-1, X-3, X-4. [pmid: 11039857].
353 Bowman LG, Piazza CC, Fisher WW, et al. Assessment of preference for varied versus constant reinforcers. J Appl Behav Anal. Fall. 1997;30(3):451-8. X-4, X-10. [pmid: 9316258].
354 Boyd RD. Sex as a possible source of group inequivalence in Lovaas (1987). J Autism Dev Disord. 06. 1998;28(3):211-5. X-1, X-2, X-3, X-4, X-10. [pmid: 9656132].
355 Boyle C, Alexander M. Public health research at the CDC: implications for communication sciences and disorders. J Commun Disord. 07–08. 2005;38(4):263-70. X-2. [pmid: 15862809].
356 Brachlow AE, Ness KK, McPheeters ML, et al. Comparison of indicators for a primary care medical home between children with autism or asthma and other special health care needs: National Survey of Children’s Health. Arch Pediatr Adolesc Med. 04. 2007;161(4):399-405. X-4. [pmid: 17404138].
357 Brackenbury T, Burroughs E, Hewitt LE. A Qualitative Examination of Current Guidelines for Evidence-Based Practice in Child Language Intervention. Language, Speech, and Hearing Services in Schools. 01. 2008;39(1):78-88. X-1, X-3, X-4.
358 Bradstreet JJ, Smith S, Granpeesheh D, et al. Spironolactone might be a desirable immunologic and hormonal intervention in autism spectrum disorders. Med Hypotheses. 2007;68(5):979-87. X-3. [pmid: 17150311].
359 Brady NC, Steeples T, Fleming K. Effects of prelinguistic communication levels on initiation and repair of communication in children with disabilities. J Speech Lang Hear Res. 10. 2005;48(5):1098-113. X-4. [pmid: 16411798].
360 Braithwaite KL, Richdale AL. Functional communication training to replace challenging behaviors across two behavioral outcomes. Behavioral Interventions. 01–03. 2000;15(1):21-36. X-3.
361 Braman BJ, Brady MP, Linehan SL, et al. Facilitated communication for children with autism: An examination of face validity. Behavioral Disorders. Special Issue: Autism. 11. 1995;21(1):110-118. X-10.
362 Branford D, Bhaumik S, Naik B. Selective serotonin re-uptake inhibitors for the treatment of perseverative and maladaptive behaviours of people with intellectual disability. J Intellect Disabil Res. 08. 1998;42(Pt 4):301-6. X-1, X-10. [pmid: 9786445].
363 Brasic JR, Barnett JY. Hyperkinesias in a prepubertal boy with autistic disorder treated with haloperidol and valproic acid. Psychological Reports. 02. 1997;80(1):163-170. X-3, X-10. [pmid: 9122323].
364 Brasic JR, Barnett JY, Kaplan D, et al. Clomipramine ameliorates adventitious movements and compulsions in prepubertal boys with autistic disorder and severe mental retardation. Neurology. 07. 1994;44(7):1309-12. X-3, X-10. [pmid: 8035936].
365 Brasic JR, Barnett JY, Sheitman BB, et al. Clinical assessment of adventitious movements. Psychol Rep. 12. 1998;83(3 Pt 1):739-50. X-3, X-4, X-10. [pmid: 9923147].
366 Breen C, Haring T, Pitts-Conway V, et al. The training and generalization of social interaction during breaktime at two job sites in the natural environment. Journal of the Association for Persons with Severe Handicaps. Spr. 1985;10(1):41-50. X-1, X-4, X-10.
367 Brendel DH. Complications to consent. J Clin Ethics. Spring-Summer. 2003;14(1–2):90-4. X-1, X-2, X-3, X-4. [pmid: 12953356].
368 Brian J, Bryson SE, Garon N, et al. Clinical Assessment of Autism in High-Risk 18-Month-Olds. Autism: The International Journal of Research and Practice. 2008;12(5):433-456. X-4. [pmid: 18805941].
369 Brightman RP, Baker BL, Clark DB, et al. Effectiveness of alternative parent training formats. J Behav Ther Exp Psychiatry. 06. 1982;13(2):113-7. X-10. [pmid: 6215431].
370 Briody J, McGarry K. Using social stories to ease children’s transitions. Young Children. September. 2005:1-4. X-4.
371 Bristol MM, Gallagher JJ, Holt KD. Maternal depressive symptoms in autism: Response to psychoeducational intervention. Rehabilitation Psychology. Spr. 1993;38(1):3-10. X-10.
372 Britton LN, Carr JE, Kellum KK, et al. A variation of noncontingent reinforcement in the treatment of aberrant behavior. Res Dev Disabil. 11–12. 2000;21(6):425-35. X-3. [pmid: 11153827].
373 Britton LN, Carr JE, Landaburu HJ, et al. The efficacy of non-contingent reinforcement as treatment for automatically reinforced stereotypy. Behavioral Interventions. 04–06. 2002;17(2):93-103. X-1, X-3.
374 Bro F, Mabeck CE. Prescribed daily dose of phenoxymethylpenicillin in general practice. Scand J Prim Health Care. 05. 1986;4(2):105-8. X-1, X-3, X-4, X-10. [pmid: 3088693].
375 Bro F, Mabeck CE. Use of antibiotics in general practice in Denmark. Prescribed daily dose, duration of treatment and number of treatments in general practice. Scand J Prim Health Care. 05. 1986;4(2):101-4. X-1, X-4, X-10. [pmid: 3726323].
376 Broadstock M, Doughty C, Eggleston M. Systematic Review of the Effectiveness of Pharmacological Treatments for Adolescents and Adults with Autism Spectrum Disorder. Autism: The International Journal of Research and Practice. 2007;11(4):335-348. X-2, X-3. [pmid: 17656398].
377 Broderick AA. Autism, “recovery (to normalcy),” and the politics of hope. Intellectual and Developmental Disabilities. 08. 2009;47(4):263-281. X-1, X-2, X-3, X-4. [pmid: 19650681].
378 Broderick AA, Ne’eman A. Autism as Metaphor: Narrative and Counter-Narrative. International Journal of Inclusive Education. 09. 2008;12(5–6):459-476. X-1, X-2, X-3, X-4.
379 Broderick C, Caswell R, Gregory S, et al. ‘Can I join the club?’: a social integration scheme for adolescents with Asperger syndrome. Autism. 12. 2002;6(4):427-31. X-1, X-3. [pmid: 12540132].
380 Brodkin ES, McDougle CJ, Naylor ST, et al. Clomipramine in adults with pervasive developmental disorders: a prospective open-label investigation. J Child Adolesc Psychopharmacol. Summer. 1997;7(2):109-21. X-1, X-10. [pmid: 9334896].
381 Broggi S, Cattaneo GM, Molinelli S, et al. Results of a two-year quality control program for a helical tomotherapy unit. Radiother Oncol. 02. 2008;86(2):231-41. X-4. [pmid: 18061691].
382 Bromfield R. It’s the tortoise’s race: Long-term psychodynamic psychotherapy with a high-functioning autistic adolescent. Psychoanalytic Inquiry. Special Issue: Autistic spectrum disorders and psychoanalytic ideas: Reassessing the fit. 2000;20(5):732-745. X-3.
383 Bromley BE. Broadcasting Disability: An Exploration of the Educational Potential of a Video Sharing Web Site. Journal of Special Education Technology. 2008;23(4):2008-2009. X-1, X-3, X-4.
384 Bromley RL, Mawer G, Clayton-Smith J, et al. Autism spectrum disorders following in utero exposure to antiepileptic drugs. Neurology. 12. 2. 2008;71(23):1923-4. X-3, X-4. [pmid: 19047565].
385 Bronnick K, Ehrt U, Emre M, et al. Attentional deficits affect activities of daily living in dementia-associated with Parkinson’s disease. J Neurol Neurosurg Psychiatry. 10. 2006;77(10):1136-42. X-1, X-4. [pmid: 16801351].
386 Brookman-Frazee L, Koegel RL. Using Parent/Clinician Partnerships in Parent Education Programs for Children with Autism. Journal of Positive Behavior Interventions. 2004;6(4):195-213. X-3.
387 Brookman-Frazee L, Stahmer A, Baker-Ericzen MJ, et al. Parenting Interventions for Children with Autism Spectrum and Disruptive Behavior Disorders: Opportunities for Cross-Fertilization. Clinical Child and Family Psychology Review. 12. 2006;9(3–4):181-200. X-2, X-3, X-4. [pmid: 17053963].
388 Broun L. Take the Pencil out of the Process. TEACHING Exceptional Children. 09–10. 2009;42(1):14-21. X-1, X-2, X-3, X-4.
389 Browder DM, Trela K, Jimenez B. Training Teachers to Follow a Task Analysis to Engage Middle School Students with Moderate and Severe Developmental Disabilities in Grade-Appropriate Literature. Focus on Autism and Other Developmental Disabilities. 2007;22(4):206-219. X-1, X-3.
390 Browder JA. Pediatric diagnosis and management of children with developmental disabilities. J Dev Behav Pediatr. 06. 1983;4(2):99-102. X-1, X-4, X-10. [pmid: 6192153].
391 Brower-Breitwieser CM, Miltenberger RG, Gross A, et al. The Use of Concurrent Operants Preference Assessment to Evaluate Choice of Interventions for Children Diagnosed with Autism. International Journal of Behavioral Consultation and Therapy. 2008;4(3):270-278. X-3, X-4.
392 Brown DW. Autism, Asperger’s syndrome and the Crick-Mitchison theory of the biological function of REM sleep. Med Hypotheses. 11. 1996;47(5):399-403. X-1, X-2, X-3, X-4, X-10. [pmid: 8951804].
393 Brown GE, Jones SD, MacKewn AS, et al. An exploration of possible pre- and postnatal correlates of autism: a pilot survey. Psychol Rep. 02. 2008;102(1):273-82. X-1, X-4. [pmid: 18481687].
394 Brown J, Murray D. Strategies for enhancing play skills for children with autism spectrum disorder. Education & Training in Mental Retardation & Developmental Disabilities. 09. 2001;36(3):312-317. X-1, X-2, X-3, X-4.
395 Brown KA, Wacker DP, Derby KM, et al. Evaluating the effects of functional communication training in the presence and absence of establishing operations. J Appl Behav Anal. Spring. 2000;33(1):53-71. X-3. [pmid: 10738952].
396 Brown KE, Mirenda P. Contingency Mapping: Use of a Novel Visual Support Strategy as an Adjunct to Functional Equivalence Training. Journal of Positive Behavior Interventions. Sum. 2006;8(3):155-164. X-3.
397 Brown MM. Auditory integration training and autism: Two case studies. British Journal of Occupational Therapy. 01. 1999;62(1):13-18. X-10.
398 Brown N, Panksepp J. Low-dose naltrexone for disease prevention and quality of life. Med Hypotheses. 03. 2009;72(3):333-7. X-1, X-2, X-3, X-4. [pmid: 19041189].
399 Brown WT, Cohen IL, Fisch GS, et al. High dose folic acid treatment of fragile (X) males. Am J Med Genet. 01–02. 1986;23(1–2):263-71. X-1, X-3, X-10. [pmid: 3513568].
400 Browne ME. Communicating with the child who has autistic spectrum disorder: a practical introduction. Paediatr Nurs. 02. 2006;18(1):14-7. X-1, X-2, X-3, X-4.
401 Brownell MD. Musically adapted social stories to modify behaviors in students with autism: Four case studies. Journal of Music Therapy. Sum. 2002;39(2):117-144. X-3. [pmid: 12213082].
402 Browning ER. A memory pacer for improving stimulus generalization. J Autism Dev Disord. 12. 1983;13(4):427-32. X-10. [pmid: 6662845].
403 Bruck M, London K, Landa R, et al. Autobiographical memory and suggestibility in children with autism spectrum disorder. Dev Psychopathol. Winter. 2007;19(1):73-95. X-4. [pmid: 17241485].
404 Brudnak MA. Application of genomeceuticals to the molecular and immunological aspects of autism. Med Hypotheses. 08. 2001;57(2):186-91. X-1, X-2, X-3, X-4. [pmid: 11461171].
405 Brudnak MA. Probiotics as an adjuvant to detoxification protocols. Med Hypotheses. 05. 2002;58(5):382-5. X-2, X-3, X-4. [pmid: 12056873].
406 Brudnak MA, Rimland B, Kerry RE, et al. Enzyme-based therapy for autism spectrum disorders -- is it worth another look?. Med Hypotheses. 05. 2002;58(5):422-8. X-1, X-3. [pmid: 12056881].
407 Bruinsma Y, Koegel RL, Koegel LK. Joint Attention and Children with Autism: A Review of the Literature. Mental Retardation and Developmental Disabilities Research Reviews. 2004;10(3):169-175. X-1, X-2, X-3, X-4. [pmid: 15611988].
408 Brulotte J, Bukutu C, Vohra S. Complementary, holistic, and integrative medicine: fish oils and neurodevelopmental disorders. Pediatr Rev. 04. 2009;30(4):e29-33. X-1, X-2, X-3, X-4. [pmid: 19339384].
409 Bruneau N, Barthelemy C, Roux S, et al. Auditory evoked potential modifications according to clinical and biochemical responsiveness to fenfluramine treatment in children with autistic behavior. Neuropsychobiology. 1989;21(1):48-52. X-10. [pmid: 2682347].
410 Bruneau N, Garreau B, Roux S, et al. Modulation of auditory evoked potentials with increasing stimulus intensity in autistic children. Electroencephalogr Clin Neurophysiol Suppl. 1987;40:584-9. X-10. [pmid: 3480179].
411 Bruneau N, Roux S, Adrien JL, et al. Auditory associative cortex dysfunction in children with autism: evidence from late auditory evoked potentials (N1 wave-T complex). Clin Neurophysiol. 11. 1999;110(11):1927-34. X-4, X-10. [pmid: 10576489].
412 Brunner DL, Seung H. Evaluation of the Efficacy of Communication-Based Treatments for Autism Spectrum Disorders: A Literature Review. Communication Disorders Quarterly. 2009;31(1):15-41. X-1, X-2, X-3, X-4.
413 Brusa E, Richman D. Developing Stimulus Control for Occurrences of Stereotypy Exhibited by a Child with Autism. International Journal of Behavioral Consultation and Therapy. 2008;4(3):264-269. X-3.
414 Bryan LC, Gast DL. Teaching on-task and on-schedule behaviors to high-functioning children with autism via picture activity schedules. Journal of Autism and Developmental Disorders. 12. 2000;30(6):553-567. X-3. [pmid: 11261467].
415 Bryson SA, Corrigan SK, McDonald TP, et al. Characteristics of children with autism spectrum disorders who received services through community mental health centers. Autism. 01. 2008;12(1):65-82. X-2, X-4. [pmid: 18178597].
416 Bryson SE, Koegel LK, Koegel RL, et al. Large Scale Dissemination and Community Implementation of Pivotal Response Treatment: Program Description and Preliminary Data. Research and Practice for Persons with Severe Disabilities (RPSD). Sum. 2007;32(2):142-153. X-1, X-2, X-3.
417 Bryson SE, Zwaigenbaum L, Brian J, et al. A prospective case series of high-risk infants who developed autism. J Autism Dev Disord. 01. 2007;37(1):12-24. X-3, X-4. [pmid: 17211728].
418 Bucholz JL, Brady MP. Teaching Positive Work Behavior with Literacy-Based Behavioral Interventions: An Intervention for Students and Employees with Developmental Disabilities. TEACHING Exceptional Children. 11–12. 2008;41(2):50-55. X-1, X-2, X-3, X-4.
419 Buchsbaum MS, Hollander E, Haznedar MM, et al. Effect of fluoxetine on regional cerebral metabolism in autistic spectrum disorders: a pilot study. Int J Neuropsychopharmacol. 06. 2001;4(2):119-25. X-1, X-3. [pmid: 11466160].
420 Buchwald JS, Erwin R, Van Lancker D, et al. Midlatency auditory evoked responses: P1 abnormalities in adult autistic subjects. Electroencephalogr Clin Neurophysiol. 03–04. 1992;84(2):164-71. X-1, X-4, X-10. [pmid: 1372231].
421 Buck LA, Goldstein F, Kardeman E. Art as a means of interpersonal communication in autistic young adults. Journal of Psychology and Christianity. Fal. 1984;3(3):73-84. X-1, X-3, X-10.
422 Buck LA, Kardeman E, Goldstein F. Artistic talent in “autistic” adolescents and young adults. Empirical Studies of the Arts. 1985;3(1):81-104. X-1, X-2, X-3, X-4, X-10.
423 Buckley SD, Newchok DK. Differential impact of response effort within a response chain on use of mands in a student with autism. Res Dev Disabil. 01–02. 2005;26(1):77-85. X-3. [pmid: 15590240].
424 Buckley SD, Newchok DK. An Evaluation of Simultaneous Presentation and Differential Reinforcement with Response Cost to Reduce Packing. Journal of Applied Behavior Analysis. Fall. 2005;38(3):405. X-3. [pmid: 16270850].
425 Buckley SD, Newchok DK. Analysis and treatment of problem behavior evoked by music. Journal of Applied Behavior Analysis. Spr. 2006;39(1):141-144. X-3. [pmid: 16602395].
426 Buckley SD, Strunck PG, Newchok DK. A Comparison Of Two Multicomponent Procedures To Increase Food Consumption. Behavioral Interventions. 04. 2005;20(2):139-146. X-3.
427 Buday EM. The effects of signed and spoken words taught with music on sign and speech imitation by children with autism. Journal of Music Therapy. Fal. 1995;32(3):189-202. X-10.
428 Buffington DM, Krantz PJ, McClannahan LE, et al. Procedures for teaching appropriate gestural communication skills to children with autism. J Autism Dev Disord. 12. 1998;28(6):535-45. X-3, X-10. [pmid: 9932240].
429 Buggey T. Video Self-Modeling Applications With Students With Autism Spectrum Disorder in a Small Private School Setting. Focus on Autism and Other Developmental Disabilities. Spr. 2005;20(1):52-63. X-3.
430 Buggey T. A Picture Is Worth...: Video Self-Modeling Applications at School and Home. Journal of Positive Behavior Interventions. 2007;9(3):151-158. X-1, X-2, X-3, X-4.
431 Buggey T, Toombs K, Gardener P, et al. Training responding behaviors in students with autism: Using videotaped self-modeling. Journal of Positive Behavior Interventions. Fal. 1999;1(4):205-214. X-3, X-10.
432 Buitelaar JK. Why have drug treatments been so disappointing?. Novartis Found Symp. 2003;251:235-44. discussion 245–9, 281–97. X-1, X-2, X-3, X-4. [pmid: 14521196].
433 Buitelaar JK, Dekker ME, van Ree JM, et al. A controlled trial with ORG, 2766, an ACTH-(4–9) analog, in 50 relatively able children with autism. Eur Neuropsychopharmacol. 03. 1996;6(1):13-9. X-10. [pmid: 8866933].
434 Buitelaar JK, van der Gaag RJ, Cohen-Kettenis P, et al. A randomized controlled trial of risperidone in the treatment of aggression in hospitalized adolescents with subaverage cognitive abilities. J Clin Psychiatry. 04. 2001;62(4):239-48. X-1, X-4. [pmid: 11379837].
435 Buitelaar JK, van der Gaag RJ, van der Hoeven J. Buspirone in the management of anxiety and irritability in children with pervasive developmental disorders: results of an open-label study. J Clin Psychiatry. 02. 1998;59(2):56-9. X-10. [pmid: 9501886].
436 Buitelaar JK, van Engeland H, de Kogel CH, et al. Deficits in social behavior in autism and their modification by a synthetic adrenocorticotrophic hormone (4–9) analog. Experientia. 04. 15. 1992;48(4):391-4. X-1, X-2, X-3, X-4, X-10. [pmid: 1316288].
437 Buitelaar JK, van Engeland H, de Kogel K, et al. The adrenocorticotrophic hormone (4–9) analog ORG 2766 benefits autistic children: report on a second controlled clinical trial. J Am Acad Child Adolesc Psychiatry. 11. 1992;31(6):1149-56. X-10. [pmid: 1331023].
438 Buitelaar JK, Van Engeland H, de Kogel KH, et al. The use of adrenocorticotrophic hormone (4â€”9) analog ORG 2766 in autistic children: Effects on the organization of behavior. Biological Psychiatry. 06. 1992;31(11):1119-1129. X-10. [pmid: 1326339].
439 Buitelaar JK, van Engeland H, de Kogel KH, et al. The use of adrenocorticotrophic hormone (4–9) analog ORG 2766 in autistic children: effects on the organization of behavior. Biol Psychiatry. 06. 1. 1992;31(11):1119-29. X-10. [pmid: 1326339].
440 Buitelaar JK, van Engeland H, van Ree JM, et al. Behavioral effects of Org 2766, a synthetic analog of the adrenocorticotrophic hormone (4–9), in 14 outpatient autistic children. J Autism Dev Disord. 12. 1990;20(4):467-78. X-10. [pmid: 2177746].
441 Buitelaar JK, Willemsen-Swinkels SH. Medication treatment in subjects with autistic spectrum disorders. Eur Child Adolesc Psychiatry. 2000;9(Suppl 1):I85-97. X-1, X-2, X-3, X-4. [pmid: 11140783].
442 Burd L, Fisher W, Kerbeshian J. Pervasive developmental disorders in multiply disabled children. Rehabil Lit. 09–10. 1985;46(9–10):246-9. X-10. [pmid: 4070778].
443 Burd L, Gascon G, Kerbeshian J. Rett Syndrome: Case reports and management strategies. Neuroscience & Biobehavioral Reviews. Special Issue: Tourette’s syndrome and movement disorders. Fal-Win. 1988;12(3–4):283-287. X-1, X-3, X-4, X-10.
444 Burd L, Kerbeshian J, Westerland A, et al. Prospective long-term follow-up of patients with pervasive developmental disorders. J Child Neurol. 09. 2002;17(9):681-8. X-4. [pmid: 12503645].
445 Burd L, Stenehjem A, Franceschini LA, et al. A 15-year follow-up of a boy with pyridoxine (vitamin Bâ‚†)-dependent seizures with autism, breath holding, and severe mental retardation. Journal of Child Neurology. 11. 2000;15(11):763-765. X-1, X-3, X-4. [pmid: 11108513].
446 Burger M, Zaak D, Stief CG, et al. Photodynamic diagnostics and noninvasive bladder cancer: is it cost-effective in long-term application? A Germany-based cost analysis. Eur Urol. 07. 2007;52(1):142-7. X-1, X-4. [pmid: 17267099].
447 Burgess DC, Burgess MA, Leask J. The MMR vaccination and autism controversy in United Kingdom 1998–2005: inevitable community outrage or a failure of risk communication?. Vaccine. 05. 1. 2006;24(18):3921-8. X-1, X-2, X-3, X-4. [pmid: 16564116].
448 Burke JC, Cerniglia L. Stimulus complexity and autistic children’s responsivity: assessing and training a pivotal behavior. J Autism Dev Disord. 06. 1990;20(2):233-53. X-10. [pmid: 2347822].
449 Burke P. Listening to young people with special needs: the influence of group activities. J Intellect Disabil. 12. 2005;9(4):359-76. X-1, X-3, X-4. [pmid: 16330489].
450 Burkhart N. Understanding and managing the autistic child in the dental office. Dent Hyg (Chic). 02. 1984;58(2):60-3. X-10. [pmid: 6239794].
451 Burn D, Emre M, McKeith I, et al. Effects of rivastigmine in patients with and without visual hallucinations in dementia associated with Parkinson’s disease. Mov Disord. 11. 2006;21(11):1899-907. X-1, X-4. [pmid: 16960863].
452 Burrows KE, Adams CL. Challenges of service-dog ownership for families with autistic children: lessons for veterinary practitioners. J Vet Med Educ. Winter. 2008;35(4):559-66. X-1, X-3, X-4. [pmid: 19228909].
453 Burrows KE, Adams CL, Spiers J. Sentinels of safety: service dogs ensure safety and enhance freedom and well-being for families with autistic children. Qual Health Res. 12. 2008;18(12):1642-9. X-4. [pmid: 18955467].
454 Burt DB, Fuller SP, Lewis KR. Brief report: competitive employment of adults with autism. J Autism Dev Disord. 06. 1991;21(2):237-42. X-10. [pmid: 1864830].
455 Burt DB, Fuller SP, Lewis KR. Competitive employment of adults with autism. Journal of Autism and Developmental Disorders. 06. 1991;21(2):237-242. X-1, X-3, X-10. [pmid: 1864830].
456 Busch de Ahumada LC, Ahumada JL. From mimesis to agency: Clinical steps in the work of psychic two-ness. International Journal of Psychoanalysis. 06. 2005;86(3):721-736. X-3. [pmid: 16096072].
457 Buschbacher P, Fox L, Clarke S. Recapturing Desired Family Routines: A Parent-Professional Behavioral Collaboration. Research and Practice for Persons with Severe Disabilities (RPSD). Spr. 2004;29(1):25-39. X-3.
458 Buschbacher PW, Fox L. Understanding and intervening with the challenging behavior of young children with autism spectrum disorder. Language, Speech, and Hearing Services in Schools. 07. 2003;34(3):217-227. X-3.
459 Buschmann A, Jooss B, Rupp A, et al. Children with Developmental Language Delay at 24 Months of Age: Results of a Diagnostic Work-Up. Developmental Medicine & Child Neurology. 03. 2008;50(3):223-229. X-1, X-4. [pmid: 18266869].
460 Butler DE, Nordin IC, L’Italien YJ, et al. Amnesia-reversal activity of a series of N-[(disubstituted-amino)alkyl]-2-oxo-1-pyrrolidineacetamides, including pramiracetam. J Med Chem. 05. 1984;27(5):684-91. X-1, X-4, X-10. [pmid: 6716406].
461 Butler LR, Luiselli JK. Escape-Maintained Problem Behavior in a Child with Autism: Antecedent Functional Analysis and Intervention Evaluation of Noncontingent Escape and Instructional Fading. Journal of Positive Behavior Interventions. 2007;9(4):195-202. X-1, X-3.
462 Butter EM, Mulick JA, Metz B. Eight case reports of learning recovery in children with pervasive developmental disorders after early intervention. Behavioral Interventions. 11. 2006;21(4):227-243. X-3.
463 Butter EM, Wynn J, Mulick JA. Early intervention critical to autism treatment. Pediatr Ann. 10. 2003;32(10):677-84. X-1, X-2, X-3, X-4. [pmid: 14606218].
464 Cabay M. Brief report: a controlled evaluation of facilitated communication using open-ended and fill-in questions. J Autism Dev Disord. 08. 1994;24(4):517-27. X-10. [pmid: 7961334].
465 Caci B, D’Amico A, Cardaci M. New frontiers for psychology and education: robotics. Psychol Rep. 06. 2004;94(3 Pt 2):1372-4. X-1, X-2, X-3, X-4. [pmid: 15362418].
466 Cafiero JM. The effect of an augmentative communication intervention on the communication, behavior, and academic program of an adolescent with autism. Focus on Autism and Other Developmental Disabilities. Fal. 2001;16(3):179-189. X-1, X-3.
467 Caicedo C, Williams SH. Risperidone improves behavior in children with autism. J Fam Pract. 11. 2002;51(11):915. X-2. [pmid: 12485538].
468 Calandrillo SP. Vanishing vaccinations: why are so many Americans opting out of vaccinating their children?. Univ Mich J Law Reform. Winter. 2004;37(2):353-440. X-1, X-2, X-3, X-4. [pmid: 15568260].
469 Calder AJ, Lawrence AD, Keane J, et al. Reading the mind from eye gaze. Neuropsychologia. 2002;40(8):1129-38. X-1, X-5. [pmid: 11931917].
470 Cale SI, Carr EG, Blakeley-Smith A, et al. Context-based assessment and intervention for problem behavior in children with autism spectrum disorder. Behav Modif. 11. 2009;33(6):707-42. X-3. [pmid: 19933441].
471 Calhoun VD, Kiehl KA, Pearlson GD. Modulation of temporally coherent brain networks estimated using ICA at rest and during cognitive tasks. Hum Brain Mapp. 07. 2008;29(7):828-38. X-1, X-2, X-3, X-4. [pmid: 18438867].
472 Callahan K, Henson RK, Cowan AK. Social Validation of Evidence-Based Practices in Autism by Parents, Teachers, and Administrators. Journal of Autism and Developmental Disorders. 04. 2008;38(4):678-692. X-3, X-4. [pmid: 17924182].
473 Callahan K, Rademacher JA. Using self-management strategies to increase the on-task behavior of a student with autism. Journal of Positive Behavior Interventions. Spr. 1999;1(2):117-122. X-3, X-10.
474 Calle-Pascual AL, Vicente A, Martin-Alvarez PJ, et al. Estimation of the prevalence of diabetes mellitus diagnosed, and incidence of type 1 (insulin-dependent) diabetes mellitus in the Avila Health Care region of Spain. Diabetes Res Clin Pract. 01. 1993;19(1):75-81. X-1, X-4, X-10. [pmid: 8472622].
475 Cameron MJ, Shapiro RL, Ainsleigh SA. Bicycle Riding: Pedaling Made Possible through Positive Behavioral Interventions. Journal of Positive Behavior Interventions. 2005;7(3):153-158. X-3, X-4.
476 Campbell JM. Statistical comparison of four effect sizes for single-subject designs. Behav Modif. 03. 2004;28(2):234-46. X-1, X-2, X-4. [pmid: 14997950].
477 Campbell M, Adams P, Small AM, et al. Efficacy and safety of fenfluramine in autistic children. J Am Acad Child Adolesc Psychiatry. 07. 1988;27(4):434-9. X-10. [pmid: 3053609].
478 Campbell M, Adams P, Small AM, et al. Naltrexone in infantile autism. Psychopharmacol Bull. 1988;24(1):135-9. X-10. [pmid: 3387517].
479 Campbell M, Anderson LT, Deutsch SI, et al. Psychopharmacological treatment of children with the syndrome of autism. Pediatr Ann. 04. 1984;13(4):309-13. 316. X-10. [pmid: 6145142].
480 Campbell M, Anderson LT, Green WH. Behavior-disordered and aggressive children: new advances in pharmacotherapy. J Dev Behav Pediatr. 12. 1983;4(4):265-71. X-1, X-2, X-3, X-4, X-10. [pmid: 6582068].
481 Campbell M, Anderson LT, Small AM. Pharmacotherapy in autism: A summary of research at Bellevue/New York University. Brain Dysfunction. 11–12. 1990;3(5–6):299-307. X-10.
482 Campbell M, Anderson LT, Small AM, et al. Naltrexone in autistic children: behavioral symptoms and attentional learning. J Am Acad Child Adolesc Psychiatry. 11. 1993;32(6):1283-91. X-10. [pmid: 8282676].
483 Campbell M, Anderson LT, Small AM, et al. Naltrexone in autistic children: a double-blind and placebo-controlled study. Psychopharmacol Bull. 1990;26(1):130-5. X-10. [pmid: 2196621].
484 Campbell M, Anderson LT, Small AM, et al. The effects of haloperidol on learning and behavior in autistic children. J Autism Dev Disord. 06. 1982;12(2):167-75. X-10. [pmid: 7174605].
485 Campbell M, Armenteros JL, Malone RP, et al. Neuroleptic-related dyskinesias in autistic children: a prospective, longitudinal study. J Am Acad Child Adolesc Psychiatry. 06. 1997;36(6):835-43. X-10. [pmid: 9183140].
486 Campbell M, Cohen IL, Anderson LT. Pharmacotherapy for autistic children: a summary of research. Can J Psychiatry. 06. 1981;26(4):265-73. X-1, X-2, X-3, X-10. [pmid: 6117366].
487 Campbell M, Deutsch SI, Perry R, et al. Short-term efficacy and safety of fenfluramine in hospitalized preschool-age autistic children: an open study. Psychopharmacol Bull. 1986;22(1):141-7. X-10. [pmid: 3726060].
488 Campbell M, Harris JC. Resolved: autistic children should have a trial of naltrexone. J Am Acad Child Adolesc Psychiatry. 02. 1996;35(2):246-9. discussion 249–51. X-10. [pmid: 8720635].
489 Campbell M, Locascio JJ, Choroco MC, et al. Stereotypies and tardive dyskinesia: abnormal movements in autistic children. Psychopharmacol Bull. 1990;26(2):260-6. X-10. [pmid: 2236468].
490 Campbell M, Overall JE, Small AM, et al. Naltrexone in autistic children: an acute open dose range tolerance trial. J Am Acad Child Adolesc Psychiatry. 03. 1989;28(2):200-6. X-10. [pmid: 2925573].
491 Campbell M, Palij M. Behavioral and cognitive measures used in psychopharmacological studies of infantile autism. Psychopharmacol Bull. 1985;21(4):1047-53. X-1, X-2, X-3, X-4, X-10. [pmid: 4089099].
492 Campbell M, Perry R, Polonsky BB, et al. An open study of fenfluramine in hospitalized young autistic children. J Autism Dev Disord. 12. 1986;16(4):495-506. X-10. [pmid: 3804962].
493 Campbell M, Small AM, Palij M, et al. The efficacy and safety of fenfluramine in autistic children: preliminary analysis of a double-blind study. Psychopharmacol Bull. 1987;23(1):123-7. X-10. [pmid: 3602307].
494 Campbell RV, Lutzker JR. Using functional equivalence training to reduce severe challenging behavior: A case study. Journal of Developmental and Physical Disabilities. 09. 1993;5(3):203-216. X-3, X-10.
495 Canitano R. Clinical experience with Topiramate to counteract neuroleptic induced weight gain in 10 individuals with autistic spectrum disorders. Brain Dev. 04. 2005;27(3):228-32. X-1, X-3. [pmid: 15737706].
496 Canitano R. Self injurious behavior in autism: clinical aspects and treatment with risperidone. J Neural Transm. 03. 2006;113(3):425-31. X-3. [pmid: 16075185].
497 Cann P. Timely intervention. Nurs Stand. 04. 26–May 2. 2000;14(32):20. X-1, X-2, X-3, X-4.
498 Cantu ES, Stone JW, Wing AA, et al. Cytogenetic survey for autistic fragile X carriers in a mental retardation center. Am J Ment Retard. 01. 1990;94(4):442-7. X-4, X-10. [pmid: 2297426].
499 Caplan R, Guthrie D, Komo S. Blink rate in children with attention-deficitâ€”hyperactivity disorder. Biological Psychiatry. 06. 1996;39(12):1032-1038. X-1, X-3, X-4, X-10. [pmid: 8780838].
500 Caplan R, Guthrie D, Komo S. Blink rate in children with attention-deficit-hyperactivity disorder. Biological Psychiatry. 06. 1996;39(12):1032-1038. X-1, X-3, X-4, X-10. [pmid: 8780838].
501 Capone GT, Goyal P, Grados M, et al. Risperidone use in children with Down syndrome, severe intellectual disability, and comorbid autistic spectrum disorders: a naturalistic study. J Dev Behav Pediatr. 04. 2008;29(2):106-16. X-3. [pmid: 18349709].
502 Capute AJ, Palmer FB. A pediatric overview of the spectrum of developmental disabilities. J Dev Behav Pediatr. 06. 1980;1(2):66-9. X-1, X-2, X-3, X-4, X-10. [pmid: 6164696].
503 Carbone VJ, Morgenstern B, Zecchin-Tirri G, et al. The Role of the Reflexive Conditioned Motivating Operation (CMO-R) during Discrete Trial Instruction of Children with Autism. Journal of Early and Intensive Behavior Intervention. 2007;4(4):658-680. X-1, X-2, X-3, X-4.
504 Cardaciotto L, Herbert JD. Cognitive behavior therapy for social anxiety disorder in the context of Asperger’s syndrome: A single-subject report. Cognitive and Behavioral Practice. Win. 2004;11(1):75-81. X-1, X-3.
505 Cardinal DN, Hanson D, Wakeham J. Investigation of authorship in facilitated communication. Mental Retardation. 08. 1996;34(4):231-242. X-10. [pmid: 8828342].
506 Cardoso C, Montenegro ML. Speech and language pathology and autistic spectrum. Span J Psychol. 11. 2009;12(2):686-95. X-3. [pmid: 19899669].
507 Carey JS, Danielsen B, Junod FL, et al. The California Cardiac Surgery and Intervention Project: evolution of a public reporting program. Am Surg. 10. 2006;72(10):978-83. X-1, X-2, X-3, X-4. [pmid: 17058749].
508 Carey T, Ratliff-Schaub K, Funk J, et al. Double-blind placebo-controlled trial of secretin: effects on aberrant behavior in children with autism. J Autism Dev Disord. 06. 2002;32(3):161-7. X-3. [pmid: 12108617].
509 Carletti C, Meoli P, Cravero WR. A modified simulated annealing algorithm for parameter determination for a hybrid virtual model. Phys Med Biol. 08. 21. 2006;51(16):3941-52. X-1, X-2, X-3, X-4. [pmid: 16885616].
510 Carlson B, McLaughlin TF, Derby KM, et al. Teaching Preschool Children with Autism and Developmental Delays to Write. Electronic Journal of Research in Educational Psychology. 04. 2009;7(1):225-238. X-3.
511 Carlson GA, Mick E. Drug-induced disinhibition in psychiatrically hospitalized children. J Child Adolesc Psychopharmacol. Summer. 2003;13(2):153-63. X-1, X-3, X-4. [pmid: 12880509].
512 Carlson JI, Luiselli JK, Slyman A, et al. Choice-making as intervention for public disrobing in children with developmental disabilities. Journal of Positive Behavior Interventions. 04. 2008;10(2):86-90. X-3.
513 Carlson T, Reynolds CA, Caplan R. Case Report: Valproic Acid and Risperidone Treatment Leading to Development of Hyperammonemia and Mania. Journal of the American Academy of Child & Adolescent Psychiatry. 03. 2007;46(3):356. X-3. [pmid: 17314721].
514 Carlson TS, McGeorge CR, Halvorson S. Marriage and family therapists’ ability to diagnose Aspergers’ syndrome: A vignette study. Contemporary Family Therapy: An International Journal. 06. 2007;29(1–2):25-37. X-1, X-4.
515 Carmody DP, Moreno R, Mars AE, et al. Brief report: Brain activation to social words in a sedated child with autism. Journal of Autism and Developmental Disorders. 08. 2007;37(7):1381-1385. X-3, X-4. [pmid: 17136453].
516 Carnahan CR, Hume K, Clarke L, et al. Using Structured Work Systems to Promote Independence and Engagement for Students with Autism Spectrum Disorders. TEACHING Exceptional Children. 03–04. 2009;41(4):6-14. X-1, X-2, X-3, X-4.
517 Caronna EB, Augustyn M, Zuckerman B. Revisiting parental concerns in the age of autism spectrum disorders: the need to help parents in the face of uncertainty. Arch Pediatr Adolesc Med. 04. 2007;161(4):406-8. X-1, X-2, X-3, X-4. [pmid: 17404139].
518 Carpenter LA, Soorya L, Halpern D. Asperger’s syndrome and high-functioning autism. Pediatr Ann. 01. 2009;38(1):30-5. X-1, X-2, X-3. [pmid: 19213291].
519 Carpenter M, Pennington BF, Rogers SJ. Interrelations among social-cognitive skills in young children with autism. J Autism Dev Disord. 04. 2002;32(2):91-106. X-4. [pmid: 12058847].
520 Carr D. Effects of exemplar training in exclusion responding on auditory-visual discrimination tasks with children with autism. J Appl Behav Anal. Winter. 2003;36(4):507-24. X-3. [pmid: 14768669].
521 Carr D, Felce J. “Brief report: increase in production of spoken words in some children with autism after PECS teaching to Phase III”. J Autism Dev Disord. 04. 2007;37(4):780-7. X-6. [pmid: 17048094].
522 Carr EG, Blakeley-Smith A. Classroom intervention for illness-related problem behavior in children with developmental disabilities. Behav Modif. 11. 2006;30(6):901-24. X-3. [pmid: 17050770].
523 Carr EG, Carlson JI. Reduction of severe behavior problems in the community using a multicomponent treatment approach. J Appl Behav Anal. Summer. 1993;26(2):157-72. X-10. [pmid: 8331013].
524 Carr EG, Darcy M. Setting generality of peer modeling in children with autism. J Autism Dev Disord. 03. 1990;20(1):45-59. X-3, X-10. [pmid: 2324055].
525 Carr EG, Kemp DC. Functional equivalence of autistic leading and communicative pointing: analysis and treatment. J Autism Dev Disord. 12. 1989;19(4):561-78. X-3, X-10. [pmid: 2606885].
526 Carr EG, Kologinsky E. Acquisition of sign language by autistic children. II: Spontaneity and generalization effects. J Appl Behav Anal. Fall. 1983;16(3):297-314. X-3, X-10. [pmid: 6643322].
527 Carr EG, Kologinsky E, Leff-Simon S. Acquisition of sign language by autistic children. III: Generalized descriptive phrases. J Autism Dev Disord. 06. 1987;17(2):217-29. X-3, X-10. [pmid: 3610996].
528 Carr EG, Ladd MV, Schulte CF. Validation of the Contextual Assessment Inventory for Problem Behavior. Journal of Positive Behavior Interventions. 2008;10(2):91-104. X-4.
529 Carr EG, Levin L, McConnachie G, et al. Comprehensive multisituational intervention for problem behavior in the community: Long-term maintenance and social validation. Journal of Positive Behavior Interventions. Win. 1999;1(1):5-25. X-1, X-3, X-10.
530 Carr EG, Newsom C. Demand-related tantrums: Conceptualization and treatment. Behavior Modification. 10. 1985;9(4):403-426. X-10. [pmid: 4074291].
531 Carr EG, Owen-DeSchryver JS. Physical Illness, Pain, and Problem Behavior in Minimally Verbal People with Developmental Disabilities. Journal of Autism and Developmental Disorders. 03. 2007;37(3):413-424. X-4. [pmid: 16897378].
532 Carr EG, Pridal C, Dores PA. Speech versus sign comprehension in autistic children: analysis and prediction. J Exp Child Psychol. 06. 1984;37(3):587-97. X-10. [pmid: 6747550].
533 Carr EG, Yarbrough SC, Langdon NA. Effects of idiosyncratic stimulus variables on functional analysis outcomes. J Appl Behav Anal. Winter. 1997;30(4):673-86. X-4, X-10. [pmid: 9433791].
534 Carra AJM, Le Grice B, Blampied NM, et al. Picture exchange communication (PECS) training for young children: Does training transfer at school and to home?. Behaviour Change. 2009;26(1):3. X-3.
535 Carrington S, Graham L. Perceptions of school by two teenage boys with Asperger syndrome and their mothers: a qualitative study. Autism. 03. 2001;5(1):37-48. X-1, X-3, X-4. [pmid: 11708388].
536 Carter AS, Volkmar FR, Sparrow SS, et al. The Vineland Adaptive Behavior Scales: supplementary norms for individuals with autism. J Autism Dev Disord. 08. 1998;28(4):287-302. X-4, X-10. [pmid: 9711485].
537 Carter C, Meckes L, Pritchard L, et al. The Friendship Club: an after-school program for children with Asperger syndrome. Fam Community Health. 04–06. 2004;27(2):143-50. X-3. [pmid: 15596981].
538 Carter CM. Using choice with game play to increase language skills and interactive behaviors in children with autism. Journal of Positive Behavior Interventions. Sum. 2001;3(3):131-151. X-3.
539 Carter EW, Sisco LG, Brown L, et al. Peer Interactions and Academic Engagement of Youth with Developmental Disabilities in Inclusive Middle and High School Classrooms. American Journal on Mental Retardation. 11. 2008;113(6):479-494. X-4. [pmid: 19127658].
540 Carter J. Looking into a distorted mirror. J Clin Ethics. Spring-Summer. 2003;14(1–2):95-100. X-1, X-2, X-3, X-4. [pmid: 12953357].
541 Casaer P, Croonenberghs JAN, Lagae L, et al. Risperidone in the treatment of childhood autistic disorder: an open pilot study. Acta Neuropsychiatrica. 2002;14(5):242-249. X-3.
542 Cascade EF, Kalali AH, Feifel D. Treatment of autistic children. Psychiatry. 02. 2008;5(2):35-37. X-1, X-2, X-3, X-4.
543 Cascella PW, Colella CS. Knowledge of Autism Spectrum Disorders Among Connecticut School Speech-Language Pathologists. Focus on Autism and Other Developmental Disabilities. Win. 2004;19(4):245-252. X-1, X-4.
544 Case-Smith J, Arbesman M. Evidence-based review of interventions for autism used in or of relevance to occupational therapy. Am J Occup Ther. 07–08. 2008;62(4):416-29. X-1, X-2, X-3. [pmid: 18712004].
545 Case-Smith J, Bryan T. The effects of occupational therapy with sensory integration emphasis on preschool-age children with autism. Am J Occup Ther. 09–10. 1999;53(5):489-97. X-10. [pmid: 10500857].
546 Case-Smith J, Miller H. Occupational therapy with children with pervasive developmental disorders. Am J Occup Ther. 09–10. 1999;53(5):506-13. X-1, X-4, X-10. [pmid: 10500859].
547 Casey BJ, Gordon CT, Mannheim GB, et al. Dysfunctional attention in autistic savants. J Clin Exp Neuropsychol. 11. 1993;15(6):933-46. X-1, X-4, X-10. [pmid: 8120129].
548 Casey SD, Merical CL. The use of functional communication training without additional treatment procedures in an inclusive school setting. Behavioral Disorders. 11. 2006;32(1):46-54. X-3.
549 Casiday RE. Children’s health and the social theory of risk: insights from the British measles, mumps and rubella (MMR) controversy. Soc Sci Med. 09. 2007;65(5):1059-70. X-1, X-4. [pmid: 17540488].
550 Cass H, Gringras P, March J, et al. Absence of urinary opioid peptides in children with autism. Arch Dis Child. 09. 2008;93(9):745-50. X-4. [pmid: 18337276].
551 Cassidy A, McConkey R, Truesdale-Kennedy M, et al. Preschoolers with autism spectrum disorders: The impact on families and the supports available to them. Early Child Development and Care. 02. 2008;178(2):115-128. X-1, X-4.
552 Castillo H, Patterson B, Hickey F, et al. Difference in age at regression in children with autism with and without Down syndrome. J Dev Behav Pediatr. 04. 2008;29(2):89-93. X-4. [pmid: 18367994].
553 Catania CN, Almeida D, Liu-Constant B, et al. Video Modeling to Train Staff to Implement Discrete-Trial Instruction. Journal of Applied Behavior Analysis. Sum. 2009;42(2):387-392. X-1, X-3, X-4. [pmid: 19949529].
554 Causton-Theoharis J, Ashby C, Cosier M. Islands of loneliness: exploring social interaction through the autobiographies of individuals with autism. Intellect Dev Disabil. 04. 2009;47(2):84-96. X-1, X-3, X-4. [pmid: 19368487].
555 Cazzullo AG, Musetti MC, Musetti L, et al. ÃžÂ^2^-Endorphin levels in peripheral blood mononuclear cells and long-term naltrexone treatment in autistic children. European Neuropsychopharmacology. 06. 1999;9(4):361-366. X-10. [pmid: 10422898].
556 Cazzullo AG, Musetti MC, Musetti L, et al. Beta-endorphin levels in peripheral blood mononuclear cells and long-term naltrexone treatment in autistic children. Eur Neuropsychopharmacol. 06. 1999;9(4):361-6. X-10. [pmid: 10422898].
557 Cazzullo AG, Musetti MC, Musetti L, et al. Î^2^-Endorphin levels in peripheral blood mononuclear cells and long-term naltrexone treatment in autistic children. European Neuropsychopharmacology. 06. 1999;9(4):361-366. X-10. [pmid: 10422898].
558 Cecchi V. Analysis of a little girl with an autistic syndrome. International Journal of Psycho-Analysis. 1990;71(3):403-410. X-3, X-10. [pmid: 2228440].
559 Celiberti DA, Bobo HE, Kelly KS, et al. The differential and temporal effects of antecedent exercise on the self-stimulatory behavior of a child with autism. Research in Developmental Disabilities. 03–04. 1997;18(2):139-150. X-10. [pmid: 9172282].
560 Celiberti DA, Harris SL. Behavioral intervention for siblings of children with autism: A focus on skills to enhance play. Behavior Therapy. Fal. 1993;24(4):573-599. X-3, X-4, X-10.
561 Ceravolo R, Volterrani D, Frosini D, et al. Brain perfusion effects of cholinesterase inhibitors in Parkinson’s disease with dementia. J Neural Transm. 11. 2006;113(11):1787-90. X-1, X-4. [pmid: 16758132].
562 Cermak SA, Curtin C, Bandini LG. Food Selectivity and Sensory Sensitivity in Children with Autism Spectrum Disorders. J Am Diet Assoc. 02. 2010;110(2):238-246. X-1, X-2, X-3, X-4. [pmid: 20102851].
563 Ceulemans DL, Gelders YG, Hoppenbrouwers ML, et al. Effect of serotonin antagonism in schizophrenia: a pilot study with setoperone. Psychopharmacology (Berl). 1985;85(3):329-32. X-1, X-4, X-10. [pmid: 3923519].
564 Chadwick O, Cuddy M, Kusel Y, et al. Handicaps and the development of skills between childhood and early adolescence in young people with severe intellectual disabilities. J Intellect Disabil Res. 12. 2005;49(Pt 12):877-88. X-4. [pmid: 16287477].
565 Chambres P, Auxiette C, Vansingle C, et al. Adult Attitudes toward Behaviors of a Six-Year-Old Boy with Autism. Journal of Autism and Developmental Disorders. 08. 2008;38(7):1320-1327. X-3, X-4. [pmid: 18297387].
566 Chan JM, O’Reilly MF. A Social Stories intervention package for students with autism in inclusive classroom settings. J Appl Behav Anal. Fall. 2008;41(3):405-9. X-3. [pmid: 18816978].
567 Chan JM, O’Reilly MF. A Social Stories[TM] Intervention Package with Students with Autism in Inclusive Classroom Settings. Journal of Applied Behavior Analysis. Fall. 2008;41(3):405-409. X-3. [pmid: 18816978].
568 Chandler S, Charman T, Baird G, et al. Validation of the social communication questionnaire in a population cohort of children with autism spectrum disorders. J Am Acad Child Adolesc Psychiatry. 10. 2007;46(10):1324-32. X-4. [pmid: 17885574].
569 Chandler S, Christie P, Newson E, et al. Developing a diagnostic and intervention package for 2- to 3-year-olds with autism: outcomes of the frameworks for communication approach. Autism. 03. 2002;6(1):47-69. X-6. [pmid: 11918109].
570 Chang CJ, May-Kuen Wong a A. Intraductal laser photocoagulation of the bilateral parotid ducts for reduction of drooling in patients with cerebral palsy. Plast Reconstr Surg. 04. 1. 2001;107(4):907-13. X-1, X-4. [pmid: 11252081].
571 Chaplin E, Tsakanikos E, Wright S, et al. Clinical Psychopathology, Untoward Incidents and the Use of Restrictive Procedures in Adults with Intellectual Disability. Journal of Applied Research in Intellectual Disabilities. 03. 2009;22(2):169-178. X-1, X-4.
572 Chapman S, Fisher W, Piazza CC, et al. Functional assessment and treatment of life-threatening drug ingestion in a dually diagnosed youth. Journal of Applied Behavior Analysis. Sum. 1993;26(2):255-256. X-1, X-3, X-10. [pmid: 8331021].
573 Charlop MH. The effects of echolalia on acquisition and generalization of receptive labeling in autistic children. J Appl Behav Anal. Spring. 1983;16(1):111-26. X-10. [pmid: 6833164].
574 Charlop MH, Burgio LD, Iwata BA, et al. Stimulus variation as a means of enhancing punishment effects. J Appl Behav Anal. Spring. 1988;21(1):89-95. X-3, X-10. [pmid: 3372404].
575 Charlop MH, Kurtz PF, Casey FG. Using aberrant behaviors as reinforcers for autistic children. J Appl Behav Anal. Summer. 1990;23(2):163-81. X-10. [pmid: 2373653].
576 Charlop MH, Kurtz PF, Milstein JP. Too much reinforcement, too little behavior: assessing task interspersal procedures in conjunction with different reinforcement schedules with autistic children. J Appl Behav Anal. Winter. 1992;25(4):795-808. X-3, X-10. [pmid: 1478903].
577 Charlop MH, Milstein JP. Teaching autistic children conversational speech using video modeling. J Appl Behav Anal. Fall. 1989;22(3):275-85. X-3, X-10. [pmid: 2793634].
578 Charlop MH, Schreibman L, Thibodeau MG. Increasing spontaneous verbal responding in autistic children using a time delay procedure. J Appl Behav Anal. Summer. 1985;18(2):155-66. X-3, X-10. [pmid: 4019351].
579 Charlop MH, Schreibman L, Tryon AS. Learning through observation: the effects of peer modeling on acquisition and generalization in autistic children. J Abnorm Child Psychol. 09. 1983;11(3):355-66. X-3, X-10. [pmid: 6643856].
580 Charlop MH, Trasowech JE. Increasing autistic children’s daily spontaneous speech. J Appl Behav Anal. Winter. 1991;24(4):747-61. X-3, X-10. [pmid: 1797777].
581 Charlop MH, Walsh ME. Increasing autistic children’s spontaneous verbalizations of affection: an assessment of time delay and peer modeling procedures. J Appl Behav Anal. Fall. 1986;19(3):307-14. X-3, X-10. [pmid: 3771424].
582 Charlop-Christy MH, Carpenter M, Le L, et al. Using the picture exchange communication system (PECS) with children with autism: assessment of PECS acquisition, speech, social-communicative behavior, and problem behavior. J Appl Behav Anal. Fall. 2002;35(3):213-31. X-3. [pmid: 12365736].
583 Charlop-Christy MH, Carpenter MH. Modified incidental teaching sessions: A procedure for parents to increase spontaneous speech in their children with autism. Journal of Positive Behavior Interventions. Spr. 2000;2(2):98-112. X-3.
584 Charlop-Christy MH, Daneshvar S. Using video modeling to teach perspective taking to children with autism. Journal of Positive Behavior Interventions. Win. 2003;5(1):12-21. X-3.
585 Charlop-Christy MH, Haymes LK. Using obsessions as reinforcers with and without mild reductive procedures to decrease inappropriate behaviors of children with autism. Journal of Autism and Developmental Disorders. 10. 1996;26(5):527-546. X-10. [pmid: 8906454].
586 Charlop-Christy MH, Haymes LK. Using objects of obsession as token reinforcers for children with autism. J Autism Dev Disord. 06. 1998;28(3):189-98. X-10. [pmid: 9656130].
587 Charlop-Christy MH, Kelso SE. Teaching children with autism conversational speech using a cue card/written script program. Education & Treatment of Children. 05. 2003;26(2):108-127. X-3.
588 Charlop-Christy MH, Le L, Freeman KA. A comparison of video modeling with in vivo modeling for teaching children with autism. Journal of Autism and Developmental Disorders. 12. 2000;30(6):537-552. X-3. [pmid: 11261466].
589 Charman T, Baird G, Simonoff E, et al. Efficacy of three screening instruments in the identification of autistic-spectrum disorders. Br J Psychiatry. 12. 2007;191:554-9. X-4. [pmid: 18055961].
590 Charman T, Baron-Cohen S, Swettenham J, et al. Predicting Language Outcome in Infants with Autism and Pervasive Developmental Disorder. International Journal of Language & Communication Disorders. 07. 2003;38(3):265-285. X-4. [pmid: 12851079].
591 Charman T, Howlin P, Aldred C, et al. Research into early intervention for children with autism and related disorders: methodological and design issues. Report on a workshop funded by the Wellcome Trust, Institute of Child Health. London, UK. November 2001. Autism. 06. 2003;7(2):217-25. X-1, X-2, X-3, X-4.
592 Charman T, Howlin P, Berry B, et al. Measuring developmental progress of children with autism spectrum disorder on school entry using parent report. Autism. 03. 2004;8(1):89-100. X-4. [pmid: 15070549].
593 Charman T, Swettenham J, Baron-Cohen S, et al. Infants with autism: An investigation of empathy, pretend play, joint attention, and imitation. Developmental Psychology. 09. 1997;33(5):781-789. X-10. [pmid: 9300211].
594 Charman T, Taylor E, Drew A, et al. Outcome at 7 years of children diagnosed with autism at age 2: predictive validity of assessments conducted at 2 and 3 years of age and pattern of symptom change over time. J Child Psychol Psychiatry. 05. 2005;46(5):500-13. X-4. [pmid: 15845130].
595 Chasson GS, Harris GE, Neely WJ. Cost comparison of early intensive behavioral intervention and special education for children with autism. Journal of Child and Family Studies. 06. 2007;16(3):401-413. X-1, X-3, X-4.
596 Chawarska K, Klin A, Paul R, et al. A prospective study of toddlers with ASD: short-term diagnostic and cognitive outcomes. J Child Psychol Psychiatry. 10. 2009;50(10):1235-45. X-4. [pmid: 19594835].
597 Chawarska K, Shic F. Looking but Not Seeing: Atypical Visual Scanning and Recognition of Faces in 2 and 4-Year-Old Children with Autism Spectrum Disorder. Journal of Autism and Developmental Disorders. 12. 2009;39(12):1663-1672. X-4.
598 Chazan SE. Using the Children’s Play Therapy Instrument (CPTI) to measure the development of play in simultaneous treatment: A case study. Infant Mental Health Journal. 07. 2000;21(3):211-221. X-3.
599 Chell N. Experiences of parenting young people with a diagnosis of Asperger syndrome: a focus group study. Int J Psychiatr Nurs Res. 05. 2006;11(3):1348-58. X-1, X-4. [pmid: 16776442].
600 Chen SH, Bernard-Opitz V. Comparison of personal and computer-assisted instruction for children with autism. Ment Retard. 12. 1993;31(6):368-76. X-3, X-10. [pmid: 8152382].
601 Chen WX, Wu-Li L, Wong VC. Electroacupuncture for children with autism spectrum disorder: pilot study of 2 cases. J Altern Complement Med. 10. 2008;14(8):1057-65. X-3. [pmid: 18990052].
602 Cheng CW, Cho SH, Taylor M, et al. Determination of zero-field size percent depth doses and tissue maximum ratios for stereotactic radiosurgery and IMRT dosimetry: comparison between experimental measurements and Monte Carlo simulation. Med Phys. 08. 2007;34(8):3149-57. X-1, X-2, X-3, X-4. [pmid: 17879776].
603 Cheng-Shannon J, McGough JJ, Pataki C, et al. Second-Generation Antipsychotic Medications in Children and Adolescents. Journal of Child and Adolescent Psychopharmacology. Fal. 2004;14(3):372-394. X-1, X-2, X-3. [pmid: 15650494].
604 Chessick RD. Self-analysis: a fool for a patient?. Psychoanal Rev. Fall. 1990;77(3):311-40. X-1, X-2, X-3, X-4, X-10. [pmid: 2126871].
605 Chez MG, Burton Q, Dowling T, et al. Memantine as adjunctive therapy in children diagnosed with autistic spectrum disorders: an observation of initial clinical response and maintenance tolerability. J Child Neurol. 05. 2007;22(5):574-9. X-1, X-3. [pmid: 17690064].
606 Chez MG, Chang M, Krasne V, et al. Frequency of epileptiform EEG abnormalities in a sequential screening of autistic patients with no known clinical epilepsy from 1996 to 2005. Epilepsy Behav. 02. 2006;8(1):267-71. X-4. [pmid: 16403678].
607 Chiang C-H, Soong W-T, Lin T-L, et al. Nonverbal Communication Skills in Young Children with Autism. Journal of Autism and Developmental Disorders. 11. 2008;38(10):1898-1906. X-4. [pmid: 18491223].
608 Chiang HM. Naturalistic observations of elicited expressive communication of children with autism: an analysis of teacher instructions. Autism. 03. 2009;13(2):165-78. X-4. [pmid: 19261686].
609 Chiang IT, Lee Y, Frey G, et al. Testing the Situationally Modified Social Rank Theory on Friendship Quality in Male Youth with High-Functioning Autism Spectrum Disorder. Therapeutic Recreation Journal. 2004;38(3):261-274. X-3.
610 Chin HY, Bernard-Opitz V. Teaching conversational skills to children with autism: effect on the development of a theory of mind. J Autism Dev Disord. 12. 2000;30(6):569-83. X-3. [pmid: 11261468].
611 Chiu S, Widjaja F, Bates ME, et al. Anterior cingulate volume in pediatric bipolar disorder and autism. J Affect Disord. 01. 2008;105(1–3):93-9. X-4. [pmid: 17568686].
612 Choi SH-J, Nieminen TA. Naturalistic Intervention for Asperger Syndrome: A Case Study. British Journal of Special Education. 06. 2008;35(2):85-91. X-3.
613 Chouard CH, Fugain C, Meyer B. Technique and indications for the French multichannel cochlear implant “Chorimac-12” for total deafness rehabilitation. Am J Otol. 07. 1985;6(4):291-4. X-1, X-2, X-3, X-4, X-10. [pmid: 3839632].
614 Chouard CH, Fugain C, Meyer B, et al. The Chorimac-12. A multichannel cochlear implant for total deafness. Description and clinical results. Acta Otorhinolaryngol Belg. 1985;39(4):735-48. X-1, X-2, X-3, X-4, X-10. [pmid: 3841455].
615 Choutka CM, Doloughty PT, Zirkel PA. The “Discrete Trials” of Applied Behavior Analysis for Children with Autism: Outcome-Related Factors in the Case Law. Journal of Special Education. 07. 2004;38(2):95-103. X-1, X-2.
616 Chow JC. Calculation of lateral buildup ratio using Monte Carlo simulation for electron radiotherapy. Med Phys. 01. 2007;34(1):175-82. X-1, X-3, X-4. [pmid: 17278502].
617 Chow JC, Grigorov GN. Effect of electron beam obliquity on lateral buildup ratio: a Monte Carlo dosimetry evaluation. Phys Med Biol. 07. 7. 2007;52(13):3965-77. X-1, X-3, X-4. [pmid: 17664588].
618 Christensen K, Mortensen PB. Facial clefting and psychiatric diseases: a follow-up of the Danish 1936–1987 Facial Cleft cohort. Cleft Palate Craniofac J. 07. 2002;39(4):392-6. X-1, X-4. [pmid: 12071787].
619 Christensen TJ, Ringdahl JE, Bosch JJ, et al. Constipation associated with self-injurious and aggressive behavior exhibited by a child diagnosed with autism. Education and Treatment of Children. 02. 2009;32(1):89-103. X-3.
620 Christian WP. A case study in the programming and maintenance of institutional change. Journal of Organizational Behavior Management. Fal-Win. 1983;5(3–4):99-153. X-1, X-3, X-4, X-10.
621 Christiansen AS. Persisting motor control problems in 11- to 12-year-old boys previously diagnosed with deficits in attention, motor control and perception (DAMP). Dev Med Child Neurol. 01. 2000;42(1):4-7. X-1, X-4. [pmid: 10665968].
622 Christison GW, Ivany K. Elimination Diets in Autism Spectrum Disorders: Any Wheat Amidst the Chaff?. Journal of Developmental & Behavioral Pediatrics. 04. 2006;27(Suppl2):S162-S171. X-1, X-2, X-3. [pmid: 16685183].
623 Christodulu KV, Durand VM. Reducing Bedtime Disturbance and Night Waking Using Positive Bedtime Routines and Sleep Restriction. Focus on Autism and Other Developmental Disabilities. 09. 2004;19(3):130-139. X-3.
624 Chuang CF, Verhey LJ, Xia P. Investigation of the use of MOSFET for clinical IMRT dosimetric verification. Med Phys. 06. 2002;29(6):1109-15. X-1, X-3, X-4. [pmid: 12094980].
625 Chugani HT, Da Silva E, Chugani DC. Infantile spasms: III. Prognostic implications of bitemporal hypometabolism on positron emission tomography. Ann Neurol. 05. 1996;39(5):643-9. X-4, X-10. [pmid: 8619550].
626 Chung KM, Reavis S, Mosconi M, et al. Peer-mediated social skills training program for young children with high-functioning autism. Res Dev Disabil. 07–09. 2007;28(4):423-36. X-3. [pmid: 16901676].
627 Chung SY, Luk SL, Lee PW. A follow-up study of infantile autism in Hong Kong. J Autism Dev Disord. 06. 1990;20(2):221-32. X-4, X-10. [pmid: 2347821].
628 Chungpaibulpatana J, Sumpatanarax T, Thadakul N, et al. Hyperbaric oxygen therapy in Thai autistic children. J Med Assoc Thai. 08. 2008;91(8):1232-8. X-3. [pmid: 18788696].
629 Church CC, Coplan J. The high-functioning autistic experience: birth to preteen years. J Pediatr Health Care. 01–02. 1995;9(1):22-9. X-4, X-10. [pmid: 7745522].
630 Chuthapisith J, diMambro B, Doody G. Effectiveness of a computer assisted learning (CAL) package to raise awareness of autism. BMC Med Educ. 2009;9:12. X-1, X-4. [pmid: 19245703].
631 Cicero FR, Pfadt A. Investigation of a reinforcement-based toilet training procedure for children with autism. Res Dev Disabil. 09–10. 2002;23(5):319-31. X-3. [pmid: 12401483].
632 Ciesielski KT, Harris RJ, Hart BL, et al. Cerebellar hypoplasia and frontal lobe cognitive deficits in disorders of early childhood. Neuropsychologia. 05. 1997;35(5):643-55. X-1, X-4, X-10. [pmid: 9153027].
633 Ciesielski KT, Knight JE, Prince RJ, et al. Event-related potentials in cross-modal divided attention in autism. Neuropsychologia. 02. 1995;33(2):225-46. X-4, X-10. [pmid: 7746366].
634 Cimera RE, Cowan RJ. The costs of services and employment outcomes achieved by adults with autism in the US. Autism. 05. 2009;13(3):285-302. X-1, X-4. [pmid: 19369389].
635 Cipani E, Brendlinger J, McDowell L, et al. Continuous vs. intermittent punishment: A case study. Journal of Developmental and Physical Disabilities. 06. 1991;3(2):147-156. X-1, X-3, X-10.
636 Clancy F. Sensory mystery. Minn Med. 11. 2002;85(11):22-8. X-1, X-2, X-3, X-4.
637 Clancy F. Desperately seeking solutions. Minn Med. 03. 2006;89(3):30-5. 51. X-1, X-2, X-3, X-4.
638 Clark E, Olympia DE, Jensen J, et al. Striving for Autonomy in a Contingency-Governed World: Another Challenge for Individuals with Developmental Disabilities. Psychology in the Schools. 01. 2004;41(1):143-153. X-2, X-3, X-4.
639 Clark KM, Green G. Comparison of two procedures for teaching dictated-word/symbol relations to learners with autism. J Appl Behav Anal. Winter. 2004;37(4):503-7. X-3. [pmid: 15669408].
640 Clarke JC, Thomason S. The use of an aversive smell to eliminate autistic self-stimulatory behavior. Child & Family Behavior Therapy. Fal. 1983;5(3):51-67. X-3, X-10.
641 Clarke S, Dunlap G, Vaughn B. Family-centered, assessment-based intervention to improve behavior during an early morning routine. Journal of Positive Behavior Interventions. Fal. 1999;1(4):235-241. X-3, X-10.
642 Clarkson G. The spiritual insights of a Guided Imagery and Music client with autism. Journal of the Association for Music & Imagery. 1998;6:87-103. X-1, X-3, X-4, X-10.
643 Clifford S, Dissanayake C, Bui QM, et al. Autism spectrum phenotype in males and females with fragile X full mutation and premutation. J Autism Dev Disord. 04. 2007;37(4):738-47. X-4. [pmid: 17031449].
644 Coben R, Linden M, Myers TE. Neurofeedback for Autistic Spectrum Disorder: A Review of the Literature. Appl Psychophysiol Biofeedback. 2009. 10. 24. X-1, X-2, X-3.
645 Coben R, Padolsky I. Infrared imaging and neurofeedback: Initial reliability and validity. Journal of Neurotherapy. 2007;11(3):3-13. X-1, X-3, X-4.
646 Cocchi R. Drug therapies for sleep troubles, hyperactivity and aggression in young adult autistics. Italian Journal of Intellective Impairment. 12. 1995;8(2):169-173. X-1, X-3, X-10.
647 Cocchi R. A work in progress on drug therapy of an autistic child aged three: 1. The first six months’ therapy. Italian Journal of Intellective Impairment. 12. 1995;8(2):175-183. X-3, X-10.
648 Cocchi R. A work in progress on drug therapy of an autistic child aged three (at first consultation): 2. The second six-months’ therapy. Italian Journal of Intellective Impairment. 06. 1996;9(1):31-40. 93. 102. X-3, X-10.
649 Cocchi R. A work in progress on drug therapy of an autistic child aged three (at first consultation): 3. The third six-months’ therapy. Italian Journal of Intellective Impairment. 12. 1996;9(2):189-196. 259. 267. X-3, X-10.
650 Coe D, Matson J, Fee V, et al. Training nonverbal and verbal play skills to mentally retarded and autistic children. J Autism Dev Disord. 06. 1990;20(2):177-87. X-3, X-10. [pmid: 2347818].
651 Coe DA, Matson JL, Craigie CJ, et al. Play skills of autistic children: Assessment and instruction. Child & Family Behavior Therapy. 1991;13(3):13-40. X-10.
652 Coffin CM, Lowichik A, Putnam A. Lipoblastoma (LPB): a clinicopathologic and immunohistochemical analysis of 59 cases. Am J Surg Pathol. 11. 2009;33(11):1705-12. X-1, X-3, X-4. [pmid: 19738456].
653 Coggins TE, Morisset C, Krasney L, et al. Brief report: does fenfluramine treatment enhance the cognitive and communicative functioning of autistic children?. J Autism Dev Disord. 09. 1988;18(3):425-34. X-10. [pmid: 3170458].
654 Cohen D, Jay SM. Autistic barriers in the psychoanalysis of borderline adults. International Journal of Psycho-Analysis. 10. 1996;77(5):913-933. X-1, X-3, X-4, X-10. [pmid: 8933218].
655 Cohen D, Nicoulaud L, Maturana A, et al. Investigating the use of packing therapy in adolescents with catatonia: A retrospective study. Clinical Neuropsychiatry: Journal of Treatment Evaluation. 02. 2009;6(1):29-34. X-1, X-3, X-4.
656 Cohen IL. Criterion-related validity of the PDD Behavior Inventory. Journal of Autism and Developmental Disorders. 02. 2003;33(1):47-53. X-4. [pmid: 12708579].
657 Cohen IL, Campbell M, Posner D. A study of haloperidol in young autistic children: a within-subjects design using objective rating scales. Psychopharmacol Bull. 07. 1980;16(3):63-5. X-10.
658 Cohen IL, Campbell M, Posner D, et al. Behavioral effects of haloperidol in young autistic children. An objective analysis using a within-subjects reversal design. J Am Acad Child Psychiatry. Autumn. 1980;19(4):665-77. X-10. [pmid: 7204797].
659 Cohen IL, Liu X, Schutz C, et al. Association of autism severity with a monoamine oxidase A functional polymorphism. Clin Genet. 09. 2003;64(3):190-7. X-4. [pmid: 12919132].
660 Cohen IL, Schmidt-Lackner S, Romanczyk R, et al. The PDD Behavior Inventory: a rating scale for assessing response to intervention in children with pervasive developmental disorder. J Autism Dev Disord. 02. 2003;33(1):31-45. X-1, X-3, X-4. [pmid: 12708578].
661 Cohen SA, Fitzgerald BJ, Khan SR, et al. The effect of a switch to ziprasidone in an adult population with autistic disorder: chart review of naturalistic, open-label treatment. J Clin Psychiatry. 01. 2004;65(1):110-3. X-1. [pmid: 14744179].
662 Collier D, Reid G. A comparison of two models designed to teach autistic children a motor task. Adapted Physical Activity Quarterly. 07. 1987;4(3):226-236. X-1, X-4, X-10.
663 Collier R. Fiction dereliction. CMAJ. 03. 11. 2008;178(6):792. X-1, X-2, X-3, X-4. [pmid: 18332395].
664 Collins BC, Evans A, Creech-Galloway C, et al. Comparison of the Acquisition and Maintenance of Teaching Functional and Core Content Sight Words in Special and General Education Settings. Focus on Autism and Other Developmental Disabilities. 2007;22(4):220-233. X-3.
665 Collins MSR, Kyle R, Smith S, et al. Coping with the usual family diet: Eating behaviour and food choices of children with Doown’s syndrome, autistic spectrum disorders or cri du chat syndrome and comparison groups of siblings. Journal of Learning Disabilities. 06. 2003;7(2):137-155. X-4.
666 Collins MSR, Laverty A, Roberts S, et al. Eating behaviour and food choices in children with Down’s syndrome, autistic spectrum disorder or cri du chat syndrome and comparison groups of siblings: Diet and preventive dentistry. Journal of Learning Disabilities. 12. 2004;8(4):331-350. X-4.
667 Colozzi GA, Ward LW, Crotty KE. Comparison of Simultaneous Prompting Procedure in 1:1 and Small Group Instruction to Teach Play Skills to Preschool Students with Pervasive Developmental Disorder and Developmental Disabilities. Education and Training in Developmental Disabilities. 06. 2008;43(2):226-248. X-3.
668 Comelli LT. The psychotherapeutic treatment of a psychotic child with marked autistic features. Psychoanalytic Psychotherapy. 1987;3(1):11-25. X-3, X-10.
669 Connor DF, McLaughlin TJ. A naturalistic study of medication reduction in a residential treatment setting. J Child Adolesc Psychopharmacol. 04. 2005;15(2):302-10. X-4. [pmid: 15910214].
670 Connors SL, Crowell DE, Eberhart CG, et al. beta2-adrenergic receptor activation and genetic polymorphisms in autism: data from dizygotic twins. J Child Neurol. 11. 2005;20(11):876-84. X-3, X-4. [pmid: 16417856].
671 Conroy MA, Asmus JM, Sellers JA, et al. The Use of an Antecedent-Based Intervention to Decrease Stereotypic Behavior in a General Education Classroom: A Case Study. Focus on Autism and Other Developmental Disabilities. Win. 2005;20(4):223-230. X-3.
672 Conroy T. What is “appropriate” for school-aged children with autism?. J S C Med Assoc. 10. 2006;102(8):285-8. X-1, X-2, X-3, X-4. [pmid: 17319246].
673 Constantino JN, Lajonchere C, Lutz M, et al. Autistic social impairment in the siblings of children with pervasive developmental disorders. Am J Psychiatry. 02. 2006;163(2):294-6. X-1, X-4. [pmid: 16449484].
674 Constantino JN, Yang D, Gray TL, et al. Clarifying the associations between language and social development in autism: a study of non-native phoneme recognition. J Autism Dev Disord. 08. 2007;37(7):1256-63. X-4. [pmid: 17080273].
675 Conti-Ramsden G, Botting N, Simkin Z, et al. Follow-up of children attending infant language units: outcomes at 11 years of age. Int J Lang Commun Disord. 04–06. 2001;36(2):207-19. X-4. [pmid: 11344595].
676 Coo H, Ouellette-Kuntz H, Lloyd JEV, et al. Trends in Autism Prevalence: Diagnostic Substitution Revisited. Journal of Autism and Developmental Disorders. 07. 2008;38(6):1036-1046. X-4. [pmid: 17975721].
677 Cook DG. A sensory approach to the treatment and management of children with autism. Focus on Autistic Behavior. 02. 1990;5(6):1-19. X-3, X-10.
678 Cook EH Jr, Anderson GM, Heninger GR, et al. Tryptophan loading in hyperserotonemic and normoserotonemic adults. Biol Psychiatry. 03. 1. 1992;31(5):525-8. X-1, X-2, X-3, X-4, X-10. [pmid: 1581428].
679 Cook EH, Rowlett R, Jaselskis C, et al. Fluoxetine treatment of children and adults with autistic disorder and mental retardation. Journal of the American Academy of Child & Adolescent Psychiatry. 07. 1992;31(4):739-745. X-10. [pmid: 1644739].
680 Cooper SA, Smiley E, Allan LM, et al. Adults with Intellectual Disabilities: Prevalence, Incidence and Remission of Self-Injurious Behaviour, and Related Factors. Journal of Intellectual Disability Research. 03. 2009;53(3):200-216. X-1, X-4. [pmid: 18444987].
681 Cooper WO, Hickson GB, Fuchs C, et al. New users of antipsychotic medications among children enrolled in TennCare. Arch Pediatr Adolesc Med. 08. 2004;158(8):753-9. X-4. [pmid: 15289247].
682 Coplan J, Souders MC, Mulberg AE, et al. Children with autistic spectrum disorders. II: parents are unable to distinguish secretin from placebo under double-blind conditions. Arch Dis Child. 08. 2003;88(8):737-9. X-4. [pmid: 12876178].
683 Coppola G, Plouin P, Chiron C, et al. Migrating partial seizures in infancy: a malignant disorder with developmental arrest. Epilepsia. 10. 1995;36(10):1017-24. X-4, X-10. [pmid: 7555952].
684 Corbett B, Khan K, Czapansky-Beilman D, et al. A double-blind, placebo-controlled crossover study investigating the effect of porcine secretin in children with autism. Clin Pediatr (Phila). 06. 2001;40(6):327-31. X-3. [pmid: 11824175].
685 Corbett BA, Kantor AB, Schulman H, et al. A proteomic study of serum from children with autism showing differential expression of apolipoproteins and complement proteins. Molecular Psychiatry. 03. 2007;12(3):292-306. X-4. [pmid: 17189958].
686 Corbett BA, Mendoza S, Abdullah M, et al. Cortisol circadian rhythms and response to stress in children with autism. Psychoneuroendocrinology. 01. 2006;31(1):59-68. X-4. [pmid: 16005570].
687 Cordisco LK, Strain PS, Depew N. Assessment for generalization of parenting skills in home settings. Journal of the Association for Persons with Severe Handicaps. Fal. 1988;13(3):202-210. X-1, X-3, X-4, X-10.
688 Cornish E. Gluten and casein free diets in autism: a study of the effects on food choice and nutrition. J Hum Nutr Diet. 08. 2002;15(4):261-9. X-4. [pmid: 12153499].
689 Corson AH, Barkenbus JE, Posey DJ, et al. A retrospective analysis of quetiapine in the treatment of pervasive developmental disorders. J Clin Psychiatry. 11. 2004;65(11):1531-6. X-1, X-3. [pmid: 15554768].
690 Cosden M, Koegel LK, Koegel RL, et al. Strength-Based Assessment for Children with Autism Spectrum Disorders. Research and Practice for Persons with Severe Disabilities (RPSD). Sum. 2006;31(2):134-143. X-2, X-3, X-4.
691 Coskun M, Karakoc S, Kircelli F, et al. Effectiveness of mirtazapine in the treatment of inappropriate sexual behaviors in individuals with autistic disorder. J Child Adolesc Psychopharmacol. 04. 2009;19(2):203-6. X-1, X-3. [pmid: 19364298].
692 Costa RM, de Carvalho LA, Drummond R, et al. The UFRJ-UERJ group: interdisciplinary virtual reality experiments in neuropsychiatry. Cyberpsychol Behav. 10. 2002;5(5):423-31. X-1, X-2, X-3, X-4. [pmid: 12448779].
693 Costello EJ, Loeber R, Stouthamer-Loeber M. Pervasive and situational hyperactivity--confounding effect of informant: a research note. J Child Psychol Psychiatry. 01. 1991;32(2):367-76. X-4, X-10. [pmid: 2033114].
694 Couper J. Who should pay for intensive behavioural intervention in autism? A parent’s view. J Paediatr Child Health. 09–10. 2004;40(9–10):559-61. X-1, X-2, X-3, X-4. [pmid: 15367153].
695 Courchesne E, Townsend J, Akshoomoff NA, et al. Impairment in shifting attention in autistic and cerebellar patients. Behav Neurosci. 10. 1994;108(5):848-65. X-1, X-2, X-3, X-4, X-10. [pmid: 7826509].
696 Coury D. Medical treatment of autism spectrum disorders. Curr Opin Neurol. 2010. 01. 16. X-1, X-2, X-3.
697 Couture SM, Roberts DL, Penn DL, et al. Do baseline client characteristics predict the therapeutic alliance in the treatment of schizophrenia?. J Nerv Ment Dis. 01. 2006;194(1):10-4. X-1, X-2, X-3, X-4. [pmid: 16462549].
698 Couturier JL, Nicolson R. A retrospective assessment of citalopram in children and adolescents with pervasive developmental disorders. J Child Adolesc Psychopharmacol. Fall. 2002;12(3):243-8. X-3. [pmid: 12427298].
699 Cowan RJ, Allen KD. Using Naturalistic Procedures to Enhance Learning in Individuals with Autism: A Focus on Generalized Teaching within the School Setting. Psychology in the Schools. 09. 2007;44(7):701-715. X-2, X-3.
700 Cox AL, Gast DL, Luscre D, et al. The Effects of Weighted Vests on Appropriate In-Seat Behaviors of Elementary-Age Students with Autism and Severe to Profound Intellectual Disabilities. Focus on Autism and Other Developmental Disabilities. 2009;24(1):17-26. X-3.
701 Coyle C, Cole P. A videotaped self-modelling and self-monitoring treatment program to decrease off-task behaviour in children with autism. Journal of Intellectual & Developmental Disability. 03. 2004;29(1):3-15. X-3.
702 Cozzi L, Nicolini G, Vanetti E, et al. Basic dosimetric verification in water of the anisotropic analytical algorithm for Varian, Elekta and Siemens linacs. Z Med Phys. 2008;18(2):128-35. X-1, X-2, X-3, X-4. [pmid: 18705613].
703 Craig HK, Telfer AS. Hyperlexia and Autism Spectrum Disorder: A Case Study of Scaffolding Language Growth over Time. Topics in Language Disorders. 10–12. 2005;25(4):364-374. X-3.
704 Crescentini F. The autistic syndrome and endogenous ion cyclotron resonance: state of the art. Electromagn Biol Med. 2007;26(4):305-9. X-3. [pmid: 18097818].
705 Crews WD, Sanders EC, Hensley LG, et al. An evaluation of facilitated communication in a group of nonverbal individuals with mental retardation. Journal of Autism and Developmental Disorders. 04. 1995;25(2):205-213. X-10. [pmid: 7559286].
706 Crockett JL, Fleming RK, Doepke KJ, et al. Parent training: acquisition and generalization of discrete trials teaching skills with parents of children with autism. Res Dev Disabil. 01–02. 2007;28(1):23-36. X-1, X-3. [pmid: 16338118].
707 Croen LA, Najjar DV, Ray GT, et al. A comparison of health care utilization and costs of children with and without autism spectrum disorders in a large group-model health plan. Pediatrics. 10. 2006;118(4):e1203-11. X-4. [pmid: 17015508].
708 Croen LA, Najjar DV, Ray GT, et al. A Comparison of Health Care Utilization and Costs of Children with and without Autism Spectrum Disorders in a Large Group-Model Health Plan. Journal of the American Academy of Child & Adolescent Psychiatry. 04. 2007;46(4):523. X-4.
709 Crollick JL, Mancil GR, Stopka C. Physical Activity for Children With Autism Spectrum Disorder. Teaching Elementary Physical Education. 03. 2006;17(2):30-34. X-1, X-2, X-3, X-4.
710 Crooke PJ, Hendrix RE, Rachman JY. Brief Report: measuring the effectiveness of teaching social thinking to children with Asperger syndrome (AS) and High Functioning Autism (HFA). J Autism Dev Disord. 03. 2008;38(3):581-91. X-3. [pmid: 18026829].
711 Croonenberghs J, Fegert JM, Findling RL, et al. Risperidone in children with disruptive behavior disorders and subaverage intelligence: a 1-year, open-label study of 504 patients. J Am Acad Child Adolesc Psychiatry. 01. 2005;44(1):64-72. X-1. [pmid: 15608545].
712 Croonenberghs J, Verkerk R, Scharpe S, et al. Serotonergic disturbances in autistic disorder: L-5-hydroxytryptophan administration to autistic youngsters increases the blood concentrations of serotonin in patients but not in controls. Life Sciences. 03. 2005;76(19):2171-2183. X-1, X-4. [pmid: 15733932].
713 Crosland KA, Zarcone JR, Lindauer SE, et al. Use of Functional Analysis Methodology in the Evaluation of Medication Effects. Journal of Autism and Developmental Disorders. 06. 2003;33(3):271-279. X-3. [pmid: 12908830].
714 Crozier S, Tincani M. Effects of Social Stories on prosocial behavior of preschool children with autism spectrum disorders. Journal of Autism and Developmental Disorders. 10. 2007;37(9):1803-1814. X-3. [pmid: 17165149].
715 Crozier S, Tincani MJ. Using a Modified Social Story to Decrease Disruptive Behavior of a Child With Autism. Focus on Autism and Other Developmental Disabilities. Fall. 2005;20(3):150-157. X-3.
716 Cukic M, Kalauzi A, Ilic T, et al. The influence of coil-skull distance on transcranial magnetic stimulation motor-evoked responses. Exp Brain Res. 01. 2009;192(1):53-60. X-1, X-4. [pmid: 18787813].
717 Cullen L, Barlow J. ‘Kiss, cuddle, squeeze’: the experiences and meaning of touch among parents of children with autism attending a Touch Therapy Programme. J Child Health Care. 09. 2002;6(3):171-81. X-1, X-3, X-4. [pmid: 12224834].
718 Cullen LA, Barlow JH, Cushway D. Positive touch, the implications for parents and their children with autism: an exploratory study. Complement Ther Clin Pract. 08. 2005;11(3):182-9. X-4. [pmid: 16005835].
719 Cullen-Powell LA, Barlow JH, Cushway D. Exploring a massage intervention for parents and their children with autism: the implications for bonding and attachment. J Child Health Care. 12. 2005;9(4):245-55. X-4. [pmid: 16275663].
720 Cummings AR, Carr JE. Evaluating Progress in Behavioral Programs for Children with Autism Spectrum Disorders via Continuous and Discontinuous Measurement. Journal of Applied Behavior Analysis. Spr. 2009;42(1):57-71. X-3. [pmid: 19721730].
721 Curran AL, Sharples PM, White C, et al. Time costs of caring for children with severe disabilities compared with caring for children without disabilities. Dev Med Child Neurol. 08. 2001;43(8):529-33. X-4. [pmid: 11508918].
722 Curtin C, Bandini LG, Perrin EC, et al. Prevalence of overweight in children and adolescents with attention deficit hyperactivity disorder and autism spectrum disorders: a chart review. BMC Pediatr. 2005;5:48. X-4. [pmid: 16371155].
723 Curtis J. Patient education. Autism. Aust Fam Physician. 07. 1993;22(7):1239. X-1, X-2, X-3, X-4, X-10. [pmid: 8373315].
724 Curtis K. An Unusual Case of Recurrent Emesis in a Patient with Autistic Disorder. Mental Health Aspects of Developmental Disabilities. 01–03. 2005;8(1):1-4. X-3.
725 Cuvo AJ, Vallelunga LR. A Transactional Systems Model of Autism Services. Behavior Analyst. Fall. 2007;30(2):161-180. X-2, X-3, X-4.
726 Dadds M, Schwartz S, Adams T, et al. The effects of social context and verbal skill on the stereotypic and task-involved behaviour of autistic children. J Child Psychol Psychiatry. 09. 1988;29(5):669-76. X-10. [pmid: 3192667].
727 Dahlquist LM, et al. Enhancing an autistic girl’s cooperation with gynecological examinations. Clinical Pediatrics. 04. 1984;23(4):203. X-1, X-3, X-10. [pmid: 6697629].
728 Dale N, Salt A. Social Identity, Autism and Visual Impairment (VI) in the Early Years. British Journal of Visual Impairment. 2008;26(2):135-146. X-1, X-2, X-3, X-4.
729 Dales L, Hammer SJ, Smith NJ. Time trends in autism and in MMR immunization coverage in California. JAMA. 03. 7. 2001;285(9):1183-5. X-4. [pmid: 11231748].
730 Dalldorf JS, Schopler E. Diagnosis and management of autism. Compr Ther. 04. 1981;7(4):67-74. X-1, X-2, X-3, X-4, X-10. [pmid: 7237988].
731 Dalrymple NJ, Angrist MH. Toilet training a sixteen year old with autism in a natural setting. British Journal of Mental Subnormality. 07. 1988;34(2(67)):117-130. X-1, X-3, X-10.
732 Dalrymple NJ, Ruble LA. Toilet training and behaviors of people with autism: parent views. J Autism Dev Disord. 06. 1992;22(2):265-75. X-1, X-4, X-10. [pmid: 1624408].
733 Dalton R, Bolding D, Forman MA. Psychiatric hospitalization of preschool children: a follow-up study. Child Psychiatry Hum Dev. Fall. 1990;21(1):57-64. X-10. [pmid: 2397655].
734 Dalton ST, Howell CC. Autism: psychobiological perspectives. J Child Adolesc Psychiatr Ment Health Nurs. 07–09. 1989;2(3):92-6. X-1, X-2, X-3, X-4, X-10. [pmid: 2769591].
735 Daly BP, Creed T, Xanthopoulos M, et al. Psychosocial treatments for children with attention deficit/hyperactivity disorder. Neuropsychol Rev. 03. 2007;17(1):73-89. X-1, X-2, X-3, X-4. [pmid: 17260167].
736 Dammann O. Paediatric neurology: the many faces of development. Lancet Neurol. 01. 2007;6(1):12-4. X-1, X-2, X-3, X-4. [pmid: 17166793].
737 Daneshi A, Hassanzadeh S. Cochlear implantation in prelingually deaf persons with additional disability. J Laryngol Otol. 07. 2007;121(7):635-8. X-3, X-4. [pmid: 17147840].
738 Danfors T, von Knorring AL, Hartvig P, et al. Tetrahydrobiopterin in the treatment of children with autistic disorder: a double-blind placebo-controlled crossover study. J Clin Psychopharmacol. 10. 2005;25(5):485-9. X-3. [pmid: 16160627].
739 Daniels JL, Forssen U, Hultman CM, et al. Parental psychiatric disorders associated with autism spectrum disorders in the offspring. Pediatrics. 05. 2008;121(5):e1357-62. X-1, X-4. [pmid: 18450879].
740 Danielsson S, Viggedal G, Gillberg C, et al. Lack of effects of vagus nerve stimulation on drug-resistant epilepsy in eight pediatric patients with autism spectrum disorders: a prospective 2-year follow-up study. Epilepsy Behav. 02. 2008;12(2):298-304. X-3, X-4. [pmid: 18053767].
741 Danielsson S, Viggedal G, Steffenburg S, et al. Psychopathology, psychosocial functioning, and IQ before and after epilepsy surgery in children with drug-resistant epilepsy. Epilepsy Behav. 02. 2009;14(2):330-7. X-3, X-4. [pmid: 19026763].
742 Daoust A-M, Lusignan Fl-A, Braun CMJ, et al. Dream content analysis in persons with an autism spectrum disorder. Journal of Autism and Developmental Disorders. 04. 2008;38(4):634-643. X-1, X-4. [pmid: 17682931].
743 Dartnall NA, Holmes JP, Morgan SN, et al. Two-year control of behavioral symptoms with risperidone in two profoundly retarded adults with autism. Journal of Autism and Developmental Disorders. 02. 1999;29(1):87-91. X-1, X-3, X-10. [pmid: 10097998].
744 D’Ateno P, Mangiapanello K, Taylor BA. Using video modeling to teach complex play sequences to a preschooler with autism. Journal of Positive Behavior Interventions. Win. 2003;5(1):5-11. X-3.
745 Dauphin M, Kinney EM, Stromer R, et al. Using Video-Enhanced Activity Schedules and Matrix Training to Teach Sociodramatic Play to a Child with Autism. Journal of Positive Behavior Interventions. 2004;6(4):238-250. X-3.
746 Dauz-Williams PA, Harrison-Elder JA, Hill SM. Media approach to family training in behavior management: Two families. Issues in Comprehensive Pediatric Nursing. 1986;9(2):59-77. X-1, X-3, X-10. [pmid: 2420769].
747 Davanzo PA, Belin TR, Widawski MH, et al. Paroxetine treatment of aggression and self-injury in persons with mental retardation. Am J Ment Retard. 03. 1998;102(5):427-37. X-10. [pmid: 9544340].
748 Davidovitch M, Holtzman G, Tirosh E. Autism in the Haifa area--an epidemiological perspective. Isr Med Assoc J. 03. 2001;3(3):188-9. X-4. [pmid: 11303376].
749 Davidson S. Fleeting Smile. Teaching Artist Journal. 01. 2006;4(4):265-266. X-1, X-2, X-3, X-4.
750 Davies J. The role of the specialist for families with autistic children. Nurs Stand. 10. 9. 1996;11(3):36-40. X-10.
751 Davies PL, Soon PL, Young M, et al. Validity and reliability of the school function assessment in elementary school students with disabilities. Phys Occup Ther Pediatr. 2004;24(3):23-43. X-4.
752 Davis AS. The Neuropsychological Basis of Childhood Psychopathology. Psychology in the Schools. 04. 2006;43(4):503-512. X-1, X-2, X-3, X-4.
753 Davis CA, Brady MP, Hamilton R, et al. Effects of high-probability requests on the social interactions of young children with severe disabilities. Journal of Applied Behavior Analysis. Special Issue: Integrating basic and applied research. Win. 1994;27(4):619-637. X-3, X-10.
754 Davis CA, Brady MP, Williams RE, et al. Effects of high-probability requests on the acquisition and generalization of responses to requests in young children with behavior disorders. J Appl Behav Anal. Winter. 1992;25(4):905-16. X-3, X-10. [pmid: 1478913].
755 Davis NO, Carter AS. Parenting stress in mothers and fathers of toddlers with autism spectrum disorders: associations with child characteristics. J Autism Dev Disord. 08. 2008;38(7):1278-91. X-1, X-4. [pmid: 18240012].
756 Dawson G, Adams A. Imitation and social responsiveness in autistic children. J Abnorm Child Psychol. 06. 1984;12(2):209-25. X-4, X-10. [pmid: 6725782].
757 Dawson G, Ashman SB, Carver LJ. The role of early experience in shaping behavioral and brain development and its implications for social policy. Dev Psychopathol. Autumn. 2000;12(4):695-712. X-1, X-2, X-3, X-4. [pmid: 11202040].
758 Dawson G, Fernald M. Perspective-taking ability and its relationship to the social behavior of autistic children. J Autism Dev Disord. 12. 1987;17(4):487-98. X-4, X-10. [pmid: 3680151].
759 Dawson G, Galpert L. Mothers’ use of imitative play for facilitating social responsiveness and toy play in young autistic children. Development and Psychopathology. 1990;2(2):151-162. X-10.
760 Dawson G, Toth K, Abbott R, et al. Early Social Attention Impairments in Autism: Social Orienting, Joint Attention, and Attention to Distress. Developmental Psychology. 03. 2004;40(2):271-283. X-4. [pmid: 14979766].
761 Dawson G, Watling R. Interventions to facilitate auditory, visual, and motor integration in autism: A review of the evidence. Journal of Autism and Developmental Disorders. Special Issue: Treatments for people with autism and other pervasive developmental disorders: Research perspectives. 10. 2000;30(5):415-421. X-1, X-2, X-3.
762 Dawson G, Zanolli K. Early intervention and brain plasticity in autism. Novartis Found Symp. 2003;251:266-74. discussion 274–80, 281–97. X-1, X-2, X-3. [pmid: 14521198].
763 Day HM, Horner RH, O’Neill RE. Multiple functions or problem behaviors: Assessment and intervention. Journal of Applied Behavior Analysis. Special Issue: Functional analysis approaches to behavioral assessment and treatment. Sum. 1994;27(2):279-289. X-10.
764 de Bildt A, Sytema S, Kraijer D, et al. Adaptive functioning and behaviour problems in relation to level of education in children and adolescents with intellectual disability. J Intellect Disabil Res. 09. 2005;49(Pt 9):672-81. X-4. [pmid: 16108984].
765 de With K, Maier L, Steib-Bauert M, et al. Trends in antibiotic use at a university hospital: defined or prescribed daily doses? Patient days or admissions as denominator?. Infection. 04. 2006;34(2):91-4. X-1, X-4. [pmid: 16703299].
766 Dean AJ, McDermott BM, Marshall RT. PRN sedation-patterns of prescribing and administration in a child and adolescent mental health inpatient service. Eur Child Adolesc Psychiatry. 08. 2006;15(5):277-81. X-1, X-3, X-4. [pmid: 16583125].
767 Deb S, Bramble D, Drybala G, et al. Polydipsia amongst adults with a learning disability in an institution. J Intellect Disabil Res. 08. 1994;38(Pt 4):359-67. X-1, X-4, X-10.
768 DeBar LL, Lynch F, Powell J, et al. Use of psychotropic agents in preschool children: associated symptoms, diagnoses, and health care services in a health maintenance organization. Arch Pediatr Adolesc Med. 02. 2003;157(2):150-7. X-4. [pmid: 12580684].
769 Decety J, Meyer M. From emotion resonance to empathic understanding: a social developmental neuroscience account. Dev Psychopathol. Fall. 2008;20(4):1053-80. X-1, X-2, X-3, X-4. [pmid: 18838031].
770 DeGrace BW. The everyday occupation of families with children with autism. Am J Occup Ther. 09–10. 2004;58(5):543-50. X-3, X-4. [pmid: 15481781].
771 Delano M, Snell ME. The Effects of Social Stories on the Social Engagement of Children with Autism. Journal of Positive Behavior Interventions. 2006;8(1):29-42. X-3.
772 Delano ME. Improving written language performance of adolescents with Asperger syndrome. J Appl Behav Anal. Summer. 2007;40(2):345-51. X-3. [pmid: 17624076].
773 Delano ME. Use of Strategy Instruction to Improve the Story Writing Skills of a Student with Asperger Syndrome. Focus on Autism and Other Developmental Disabilities. 2007;22(4):252-258. X-3.
774 Delano ME. Video Modeling Interventions for Individuals with Autism. Remedial and Special Education. 01–02. 2007;28(1):33-42. X-1, X-2, X-3.
775 DeLeon IG, Anders BM, Rodriguez-Catter V, et al. The effects of noncontingent access to single- versus multiple-stimulus sets on self-injurious behavior. Journal of Applied Behavior Analysis. Special Issue: Establishing operations in applied behavior analysis. Win. 2000;33(4):623-626. X-3.
776 DeLeon IG, Fisher WW, Herman KM, et al. Assessment of a response bias for aggression over functionally equivalent appropriate behavior. Journal of Applied Behavior Analysis. Spr. 2000;33(1):73-77. X-3. [pmid: 10738953].
777 DeLeon IG, Fisher WW, Marhefka J-M. Decreasing Self-Injurious Behavior Associated with Awakening in a Child with Autism and Developmental Delays. Behavioral Interventions. 04. 2004;19(2):111-119. X-3.
778 DeLeon IG, Hagopian LP, Rodriguez-Catter V, et al. Increasing wearing of prescription glasses in individuals with mental retardation. J Appl Behav Anal. Spring. 2008;41(1):137-42. X-1, X-3. [pmid: 18468288].
779 DeLeon IG, Neidert PL, Anders BM, et al. Choices between positive and negative reinforcement during treatment for escape-maintained behavior. J Appl Behav Anal. Winter. 2001;34(4):521-5. X-3. [pmid: 11800194].
780 Delgado JAP, Greer RD. The Effects of Peer Monitoring Training on the Emergence of the Capability to Learn from Observing Instruction Received by Peers. Psychological Record. Sum. 2009;59(3):407-434. X-3.
781 DelGiudice-Asch G, Simon L, Schmeidler J, et al. Brief report: a pilot open clinical trial of intravenous immunoglobulin in childhood autism. J Autism Dev Disord. 04. 1999;29(2):157-60. X-10. [pmid: 10382136].
782 DelGiudice-Asch G, Simon L, Schmeidler J, et al. A pilot open clinical trial of intravenous immunoglobulin in childhood autism. Journal of Autism and Developmental Disorders. 04. 1999;29(2):157-160. X-3, X-10. [pmid: 10382136].
783 Delinicolas EK, Young RL. Joint attention, language, social relating, and stereotypical behaviours in children with autistic disorder. Autism. 09. 2007;11(5):425-36. X-4. [pmid: 17942456].
784 DeLong GR, Teague LA, Kamran MM. Effects of fluoxetine treatment in young children with idiopathic autism. Developmental Medicine & Child Neurology. 08. 1998;40(8):551-562. X-10. [pmid: 9746008].
785 Delprato DJ. Comparisons of discrete-trial and normalized behavioral language intervention for young children with autism. J Autism Dev Disord. 06. 2001;31(3):315-25. X-1, X-2, X-3, X-4. [pmid: 11518484].
786 DeMattei R, Cuvo A, Maurizio S. Oral assessment of children with an autism spectrum disorder. J Dent Hyg. Summer. 2007;81(3):65. X-4. [pmid: 17908421].
787 Demb HB, Roychoudhury K. Comments on “Olanzapine treatment of children, adolescents, and adults with pervasive developmental disorders: an open-label pilot study”. J Clin Psychopharmacol. 10. 2000;20(5):580-1. X-1, X-2, X-3, X-4. [pmid: 11001245].
788 DeMore M, Cataldo M, Tierney E, et al. Behavioral approaches to training developmentally disabled children for an overnight EEG procedure. Journal of Developmental and Physical Disabilities. 08. 2009;21(4):245-251. X-1, X-4. [pmid: 20617101].
789 DeMyer MK, Hingtgen JN, Jackson RK. Infantile autism reviewed: a decade of research. Schizophr Bull. 1981;7(3):388-451. X-1, X-2, X-3, X-4, X-10. [pmid: 6116276].
790 DeMyer W, DeMyer M. Infantile autism. Neurol Clin. 02. 1984;2(1):139-52. X-1, X-2, X-3, X-4, X-10. [pmid: 6503931].
791 Dennis M, Lockyer L, Lazenby AL, et al. Intelligence patterns among children with high-functioning autism, phenylketonuria, and childhood head injury. J Autism Dev Disord. 02. 1999;29(1):5-17. X-1, X-2, X-3, X-4, X-10. [pmid: 10097991].
792 DeQuinzio JA, Townsend DB, Poulson CL. The Effects of Forward Chaining and Contingent Social Interaction on the Acquisition of Complex Sharing Responses by Children with Autism. Research in Autism Spectrum Disorders. 04–06. 2008;2(2):264-275. X-3.
793 DeQuinzio JA, Townsend DB, Sturmey P, et al. Generalized imitation of facial models by children with autism. J Appl Behav Anal. Winter. 2007;40(4):755-9. X-3. [pmid: 18189112].
794 DeStefano F, Bhasin TK, Thompson WW, et al. Age at first measles-mumps-rubella vaccination in children with autism and school-matched control subjects: a population-based study in metropolitan atlanta. Pediatrics. 02. 2004;113(2):259-66. X-4. [pmid: 14754936].
795 DeStefano F, Chen RT. Autism and measles, mumps, and rubella vaccine: No epidemiological evidence for a causal association. J Pediatr. 01. 2000;136(1):125-6. X-1, X-2, X-3, X-4.
796 DeThorne LS, Johnson CJ, Walder L, et al. When “Simon says” doesn’t work: alternatives to imitation for facilitating early speech development. Am J Speech Lang Pathol. 05. 2009;18(2):133-45. X-1, X-2, X-3. [pmid: 18930909].
797 Dettmer S, Simpson RL, Myles BS, et al. The use of visual supports to facilitate transitions of students with autism. Focus on Autism and Other Developmental Disabilities. Fal. 2000;15(3):163-169. X-3.
798 Deurell M, Weischer M, Pagsberg AK, et al. The use of antipsychotic medication in child and adolescent psychiatric treatment in Denmark. A cross-sectional survey. Nord J Psychiatry. 2008;62(6):472-80. X-4. [pmid: 18841508].
799 Deutsch SI. Rationale for the administration of opiate antagonists in treating infantile autism. Am J Ment Defic. 05. 1986;90(6):631-5. X-1, X-2, X-3, X-4, X-10. [pmid: 2872816].
800 Deutsch SI, Campbell M. Relative affinities for different classes of neurotransmitter receptors predict neuroleptic efficacy in infantile autism: a hypothesis. Neuropsychobiology. 1986;15(3–4):160-4. X-10. [pmid: 2431345].
801 Deutsch SI, Campbell M, Perry R, et al. Plasma growth hormone response to insulin-induced hypoglycemia in infantile autism: a pilot study. J Autism Dev Disord. 03. 1986;16(1):59-68. X-3, X-4, X-10. [pmid: 2870051].
802 Deutsch SI, Milstoc M, Platovsky G, et al. Cholinesterase activities in blood in infantile autism. Biol Psychiatry. 02. 1987;22(2):234-6. X-4, X-10. [pmid: 3814674].
803 Devlin S, Healy O, Leader G, et al. The Analysis and Treatment of Problem Behavior Evoked by Auditory Stimulation. Research in Autism Spectrum Disorders. 10. 2008;2(4):671-680. X-3.
804 Devlin S, Leader G, Healy O. Comparison of Behavioral Intervention and Sensory-Integration Therapy in the Treatment of Self-Injurious Behavior. Research in Autism Spectrum Disorders. 01. 2009;3(1):223-231. X-3.
805 Devlin SD, Harber MM. Collaboration among Parents and Professionals with Discrete Trial Training in the Treatment for Autism. Education and Training in Developmental Disabilities. 12. 2004;39(4):291-300. X-3.
806 Dhossche DM, Stanfill S. Could ECT be effective in autism?. Med Hypotheses. 2004;63(3):371-6. X-1, X-2, X-3, X-4. [pmid: 15288351].
807 Di Martino A, Melis G, Cianchetti C, et al. Methylphenidate for pervasive developmental disorders: safety and efficacy of acute single dose test and ongoing therapy: an open-pilot study. J Child Adolesc Psychopharmacol. Summer. 2004;14(2):207-18. X-3. [pmid: 15319018].
808 Dib N, Sturmey P. Reducing student stereotypy by improving teachers’ implementation of discrete-trial teaching. J Appl Behav Anal. Summer. 2007;40(2):339-43. X-3. [pmid: 17624075].
809 DiCarlo CF, Stricklin S, Banajee M, et al. Effects of manual signing on communicative verbalizations by toddlers with and without disabilities in inclusive classrooms. Journal of the Association for Persons with Severe Handicaps. Sum. 2001;26(2):120-126. X-1, X-3, X-4.
810 Dickson CA, Wang SS, Lombard KM, et al. Overselective Stimulus Control in Residential School Students with Intellectual Disabilities. Research in Developmental Disabilities: A Multidisciplinary Journal. 11–12. 2006;27(6):618-631. X-4.
811 Dickstein D. The costs of mental illness. J Am Acad Child Adolesc Psychiatry. 05. 2009;48(5):459-60. X-1, X-2, X-3, X-4. [pmid: 19395898].
812 Diehl SF, Ford CS, Federico J. The Communication Journey of a Fully d Child with an Autism Spectrum Disorder. Topics in Language Disorders. 10–12. 2005;25(4):375-387. X-3.
813 Digennaro Reed FD, Reed DD. Towards an Understanding of Evidence-Based Practice. Journal of Early and Intensive Behavior Intervention. 2008;5(2):20-29. X-1, X-2, X-3, X-4.
814 Diggle T, McConachie HR, Randle VR. Parent-mediated early intervention for young children with autism spectrum disorder. Cochrane Database Syst Rev. 2003;(1):CD003496. X-1, X-2, X-3, X-4.
815 DiLalla DL, Rogers SJ. Domains of the Childhood Autism Rating Scale: relevance for diagnosis and treatment. J Autism Dev Disord. 04. 1994;24(2):115-28. X-4, X-10. [pmid: 8040157].
816 Diler RS, Firat S, Avci A. An open-label trial of risperidone in children with autism. Current Therapeutic Research. 01. 2002;63(1):91-102. X-3.
817 Dillard JW, Elliott R, Milo T, et al. Demographics and development of fifty-eight disturbed children: A retrospective analysis. Psychology: A Journal of Human Behavior. 1985;22(1):20-26. X-10.
818 Dillenburger K, Keenan M. None of the As in ABA stand for autism: dispelling the myths. J Intellect Dev Disabil. 06. 2009;34(2):193-5. X-1, X-2, X-3, X-4. [pmid: 19404840].
819 Dillon KM, Fenlason JE, Vogel DJ. Belief in and use of a questionable technique, facilitated communication, for children with autism. Psychol Rep. 08. 1994;75(1 Pt 2):459-64. X-1, X-3, X-4, X-10. [pmid: 7809318].
820 Dimitropoulos A, Schultz RT. Food-Related Neural Circuitry in Prader-Willi Syndrome: Response to High- versus Low-Calorie Foods. Journal of Autism and Developmental Disorders. 10. 2008;38(9):1642-1653. X-1, X-4. [pmid: 18311513].
821 Dimitrova Dimitrova Z, Dumanov VG, Ivanova Petrova G. Trends in registered psychiatric morbidity and forecasting psychotropic drug needs in Bulgarian hospitals. Acta Pharm Hung. 03–05. 1997;67(2–3):73-9. X-1, X-3, X-4, X-10. [pmid: 9223757].
822 Dinca O, Paul M, Spencer NJ. Systematic review of randomized controlled trials of atypical antipsychotics and selective serotonin reuptake inhibitors for behavioural problems associated with pervasive developmental disorders. J Psychopharmacol. 09. 2005;19(5):521-32. X-2. [pmid: 16166190].
823 DiPietro E, Luiselli JK, Campbell S, et al. A Parent Survey Approach to Evaluate Public School Education of Children with Autism/Pervasive Developmental Disorder Following Center-Based Behavioral Treatment. Special Services in the Schools. 2002;18(1–2):119-131. X-4.
824 Dipipi CM, Jitendra AK, Miller JA. Reducing Repetitive Speech: Effects of Strategy Instruction. Preventing School Failure. 2001. X-1, X-3, X-4.
825 Ditterline J, Banner D, Oakland T, et al. Adaptive Behavior Profiles of Students with Disabilities. Journal of Applied School Psychology. 06. 2008;24(2):191-208. X-1, X-2, X-3, X-4.
826 Dixon MR, Cummings A. Self-control in children with autism: response allocation during delays to reinforcement. J Appl Behav Anal. Winter. 2001;34(4):491-5. X-3. [pmid: 11800188].
827 Dixon RS, Moore DW, Hartnett N, et al. Reducing inappropriate questioning behaviour in an adolescent with autism: A case study. Behaviour Change. 1995;12(3):163-166. X-1, X-3, X-10.
828 Dobson S, Upadhyaya S, McNeil J, et al. Developing an information pack for the Asian carers of people with autism spectrum disorders. Int J Lang Commun Disord. 2001;36(Suppl):216-21. X-1, X-4. [pmid: 11340785].
829 Dockrell JE, Lindsay G, Letchford B, et al. Educational provision for children with specific speech and language difficulties: perspectives of speech and language therapy service managers. Int J Lang Commun Disord. 07–08. 2006;41(4):423-40. X-1, X-4. [pmid: 16815810].
830 Dodds L, Spencer A, Shea S, et al. Validity of autism diagnoses using administrative health data. Chronic Dis Can. 2009;29(3):102-7. X-1, X-3, X-4. [pmid: 19527568].
831 Dodel R, Csoti I, Ebersbach G, et al. Lewy body dementia and Parkinson’s disease with dementia. J Neurol. 09. 2008;255(Suppl 5):39-47. X-1, X-2, X-3, X-4. [pmid: 18787881].
832 Dodge NN, Wilson GA. Melatonin for treatment of sleep disorders in children with developmental disabilities. J Child Neurol. 08. 2001;16(8):581-4. X-1, X-2, X-3, X-4. [pmid: 11510929].
833 Doey T, Handelman K, Seabrook JA, et al. Survey of atypical antipsychotic prescribing by Canadian child psychiatrists and developmental pediatricians for patients aged under 18 years. Can J Psychiatry. 06. 2007;52(6):363-8. X-1, X-3, X-4. [pmid: 17696022].
834 Doherty K, Fitzgerald M, Matthews P. Services for autism in Ireland. Irish Journal of Psychology. 2000;21(1–2):50-69. X-4.
835 Dolan MA, Mace SE. Pediatric mental health emergencies in the emergency medical services system. Pediatrics. 10. 2006;118(4):1764-7. X-1, X-2, X-3, X-4. [pmid: 17015573].
836 Dollfus S, Petit M, Garnier JP, et al. Catecholamines in autistic disorder: Effects of amisulpride and bromocriptine in a controlled crossover study. Journal of Child and Adolescent Psychopharmacology. Fal. 1993;3(3):145-156. X-3, X-4, X-10. [pmid: 19630674].
837 Dollfus S, Petit M, Menard JF, et al. Amisulpride versus bromocriptine in infantile autism: a controlled crossover comparative study of two drugs with opposite effects on dopaminergic function. J Autism Dev Disord. 03. 1992;22(1):47-60. X-3, X-10. [pmid: 1350581].
838 Dolske MC, Spollen J, McKay S, et al. A preliminary trial of ascorbic acid as supplemental therapy for autism. Prog Neuropsychopharmacol Biol Psychiatry. 09. 1993;17(5):765-74. X-10. [pmid: 8255984].
839 Domes G, Heinrichs M, Michel A, et al. Oxytocin improves “mind-reading” in humans. Biol Psychiatry. 03. 15. 2007;61(6):731-3. X-1, X-3, X-4. [pmid: 17137561].
840 Dominguez A, Ziviani J, Rodger S. Play Behaviours and Play Object P of Young Children with Autistic Disorder in a Clinical Play Environment. Autism: The International Journal of Research & Practice. 2006;10(1):53-69. X-4. [pmid: 16522710].
841 Donaldson AI, Heavner KS, Zwolan TA. Measuring progress in children with autism spectrum disorder who have cochlear implants. Arch Otolaryngol Head Neck Surg. 05. 2004;130(5):666-71. X-3. [pmid: 15148195].
842 Donnell NE. Messages through the music: Musical dialogue as a means of communicative contact. Canadian Journal of Music Therapy. 2007;13(2):74-102. X-1, X-2, X-3, X-4.
843 Donnellan AM, LaVigna GW, Zambito J, et al. A time-limited intensive intervention program model to support community placement for persons with severe behavior problems. Journal of the Association for Persons with Severe Handicaps. Fal. 1985;10(3):123-131. X-10.
844 Dooley P, Wilczenski FL, Torem C. Using an activity schedule to smooth school transitions. Journal of Positive Behavior Interventions. Win. 2001;3(1):57-61. X-3.
845 Dosreis S, Weiner CL, Johnson L, et al. Autism spectrum disorder screening and management practices among general pediatric providers. J Dev Behav Pediatr. 04. 2006;27(2 Suppl):S88-94. X-1, X-3, X-4. [pmid: 16685190].
846 Douglas EM. A personalized communication wallet. Am J Occup Ther. 02. 1993;47(2):179-80. X-10. [pmid: 8470749].
847 Dowell LR, Mahone EM, Mostofsky SH. Associations of postural knowledge and basic motor skill with dyspraxia in autism: implication for abnormalities in distributed connectivity and motor learning. Neuropsychology. 09. 2009;23(5):563-70. X-4. [pmid: 19702410].
848 Downes P, Jarvis R, Radu E, et al. Monte Carlo simulation and patient dosimetry for a kilovoltage cone-beam CT unit. Med Phys. 09. 2009;36(9):4156-67. X-1, X-2, X-3, X-4. [pmid: 19810489].
849 Doyle RL, Frazier J, Spencer TJ, et al. Donepezil in the treatment of ADHD-like symptoms in youths with pervasive developmental disorder: a case series. J Atten Disord. 02. 2006;9(3):543-9. X-3. [pmid: 16481671].
850 Dozier CL, Carr JE, Enloe K, et al. Using fixed-time schedules to maintain behavior: A preliminary investigation. Journal of Applied Behavior Analysis. Fal. 2001;34(3):337-340. X-3. [pmid: 11678529].
851 Drager KD, Postal VJ, Carrolus L, et al. The effect of aided language modeling on symbol comprehension and production in 2 preschoolers with autism. Am J Speech Lang Pathol. 05. 2006;15(2):112-25. X-3. [pmid: 16782684].
852 Drapeau M, Beretta V, de Roten Y, et al. Defense styles of pedophilic offenders. Int J Offender Ther Comp Criminol. 04. 2008;52(2):185-95. X-1, X-3, X-4. [pmid: 17875603].
853 Drasgow E, Halle JW, Ostrosky MM. Effects of differential reinforcement on the generalization of a replacement mand in three children with severe language delays. Journal of Applied Behavior Analysis. Fal. 1998;31(3):357-374. X-10. [pmid: 9757580].
854 Drasgow E, Halle JW, Phillips B. Effects of different social partners on the discriminated requesting of a young child with autism and severe language delays. Research in Developmental Disabilities. 03–04. 2001;22(2):125-139. X-3. [pmid: 11325160].
855 Drash PW, High RL, Tudor RM. Using mand training to establish an echoic repertoire in young children with autism. Analysis of Verbal Behavior. 1999;16:29-44. X-10.
856 Drew A, Baird G, Taylor E, et al. The Social Communication Assessment for Toddlers with Autism (SCATA): an instrument to measure the frequency, form and function of communication in toddlers with autism spectrum disorder. J Autism Dev Disord. 04. 2007;37(4):648-66. X-4. [pmid: 17051443].
857 Duarte-Ramos F, Cabrita J. Using a pharmaco-epidemiological approach to estimate diabetes type 2 prevalence in Portugal. Pharmacoepidemiol Drug Saf. 04. 2006;15(4):269-74. X-1, X-3, X-4. [pmid: 16294365].
858 Dube WV, McIlvane WJ. Reduction of stimulus overselectivity with nonverbal differential observing responses. J Appl Behav Anal. Spring. 1999;32(1):25-33. X-3, X-10. [pmid: 10201101].
859 Duchan JF. Issues raised by facilitated communication for theorizing and research on autism. J Speech Hear Res. 12. 1993;36(6):1108-19. X-1, X-2, X-3, X-4, X-10. [pmid: 7605401].
860 Ducharme JM, Drain TL. Errorless academic compliance training: improving generalized cooperation with parental requests in children with autism. J Am Acad Child Adolesc Psychiatry. 02. 2004;43(2):163-71. X-3. [pmid: 14726722].
861 Ducharme JM, Lucas H, Pontes E. Errorless embedding in the reduction of severe maladaptive behavior during interactive and learning tasks. Behavior Therapy. Sum. 1994;25(3):489-501. X-3, X-10.
862 Ducharme JM, Sanjuan E, Drain T. Errorless compliance training: Success-focused behavioral treatment of children with Asperger syndrome. Behavior Modification. 05. 2007;31(3):329-344. X-3. [pmid: 17438346].
863 Dudley LL, Johnson C, Barnes RS. Decreasing rumination using a starchy food satiation procedure. Behavioral Interventions. 01–03. 2002;17(1):21-29. X-3.
864 Dugan E, Kamps D, Leonard B. Effects of cooperative learning groups during social studies for students with autism and fourth-grade peers. J Appl Behav Anal. Summer. 1995;28(2):175-88. X-3, X-10. [pmid: 7601803].
865 Duggal HS, Dutta S, Sinha VK. Mood stabilizers in Asperger’s syndrome. Australian and New Zealand Journal of Psychiatry. 06. 2001;35(3):390-391. X-1, X-3.
866 Dujardin K, Devos D, Duhem S, et al. Utility of the Mattis dementia rating scale to assess the efficacy of rivastigmine in dementia associated with Parkinson’s disease. J Neurol. 09. 2006;253(9):1154-9. X-1, X-4. [pmid: 16998649].
867 Duker PC, Douwenga H, Joosten S, et al. Effects of single and repeated shock on perceived pain and startle response in healthy volunteers. Res Dev Disabil. 07–08. 2002;23(4):285-92. X-1, X-3, X-4. [pmid: 12365852].
868 Duker PC, Hendriks C, Schroen J. Effect of Wave Frequency of Clinical Electric Shock: Pain Sensation and Startle Response. Behavioral Interventions. 04. 2004;19(2):103-110. X-1, X-3, X-4.
869 Duker PC, Schaapveld M. Increasing on-task behaviour through interruption-prompting. Journal of Intellectual Disability Research. 08. 1996;40(4):291-297. X-3, X-10. [pmid: 8884583].
870 Duker PC, Welles K, Seys D, et al. Brief report: effects of fenfluramine on communicative, stereotypic, and inappropriate behaviors of autistic-type mentally handicapped individuals. J Autism Dev Disord. 09. 1991;21(3):355-63. X-10. [pmid: 1938781].
871 Dumerc C. Continuity and discontinuity in psychotherapy. International Journal of Mental Health. Fal. 1991;20(3):57-64. X-3, X-10.
872 Dunlap G. The influence of task variation and maintenance tasks on the learning and affect of autistic children. J Exp Child Psychol. 02. 1984;37(1):41-64. X-10. [pmid: 6707578].
873 Dunlap G, Dyer K, Koegel RL. Autistic self-stimulation and intertrial interval duration. Am J Ment Defic. 09. 1983;88(2):194-202. X-10. [pmid: 6638081].
874 Dunlap G, Fox L. A demonstration of behavioral support for young children with autism. Journal of Positive Behavior Interventions. Spr. 1999;1(2):77-87. X-10.
875 Dunlap G, Johnson J. Increasing the independent responding of autistic children with unpredictable supervision. Journal of Applied Behavior Analysis. Fal. 1985;18(3):227-236. X-3, X-10. [pmid: 4044456].
876 Dunlap G, Koegel RL. Motivating autistic children through stimulus variation. J Appl Behav Anal. Winter. 1980;13(4):619-27. X-10. [pmid: 7204282].
877 Dunlap G, Koegel RL, Johnson J, et al. Maintaining performance of autistic clients in community settings with delayed contingencies. J Appl Behav Anal. Summer. 1987;20(2):185-91. X-3, X-10. [pmid: 3610898].
878 Dunlap G, Robbins FR, Darrow MA. Parents’ reports of their children’s challenging behaviors: results of a statewide survey. Ment Retard. 06. 1994;32(3):206-12. X-1, X-3, X-4, X-10. [pmid: 8084272].
879 Dunn ME, Burbine T, Bowers CA, et al. Moderators of stress in parents of children with autism. Community Ment Health J. 02. 2001;37(1):39-52. X-1, X-3, X-4. [pmid: 11300666].
880 Dunn W, Myles BS, Orr S. Sensory processing issues associated with Asperger syndrome: a preliminary investigation. Am J Occup Ther. 01–02. 2002;56(1):97-102. X-4. [pmid: 11833406].
881 Dunne PB. Drama therapy techniques in one-to-one treatment with disturbed children and adolescents. The Arts in Psychotherapy. Sum. 1988;15(2):139-149. X-10.
882 Duran E. Teaching nonsheltered vocational skills to autistic adolescents and young adults. Psychology: A Journal of Human Behavior. 1984;21(3–4):49-54. X-1, X-2, X-3, X-4, X-10.
883 Duran E. Teaching moderately and severely handicapped students of limited English proficiency to do competitive employment in nonsheltered sites. Journal of Instructional Psychology. 09. 1985;12(3):127-131. X-1, X-2, X-3, X-4, X-10.
884 Duran E. Teaching functional reading in context to severely retarded and severely retarded autistic adolescents of limited English proficiency. Adolescence. Summer. 1985;20(78):433-9. X-1, X-2, X-3, X-4, X-10. [pmid: 4050577].
885 Duran E. Teaching janitorial skills to autistic adolescents. Adolescence. Spring. 1985;20(77):225-32. X-1, X-3, X-10. [pmid: 3984810].
886 Durand VM. Functional communication training using assistive devices: Recruiting natural communities of reinforcement. Journal of Applied Behavior Analysis. Fal. 1999;32(3):247-267. X-10. [pmid: 10513023].
887 Durand VM. Treating sleep terrors in children with autism. Journal of Positive Behavior Interventions. Spr. 2002;4(2):66-72. X-3.
888 Durand VM, Carr EG. Social influences on “self-stimulatory” behavior: Analysis and treatment application. Journal of Applied Behavior Analysis. Sum. 1987;20(2):119-132. X-10. [pmid: 3610892].
889 Durand VM, Carr EG. Functional communication training to reduce challenging behavior: maintenance and application in new settings. J Appl Behav Anal. Summer. 1991;24(2):251-64. X-3, X-10. [pmid: 1890046].
890 Durand VM, Carr EG. An analysis of maintenance following functional communication training. Journal of Applied Behavior Analysis. Win. 1992;25(4):777-794. X-10. [pmid: 1478902].
891 Durand VM, Christodulu KV, Koegel RL. Description of a sleep-restriction program to reduce bedtime disturbances and night waking. Journal of Positive Behavior Interventions. Spr. 2004;6(2):83-91. X-3.
892 Durand VM, Crimmins DB. Assessment and treatment of psychotic speech in an autistic child. J Autism Dev Disord. 03. 1987;17(1):17-28. X-3, X-10. [pmid: 3571140].
893 Dybvik AC. Autism and the Inclusion Mandate. Education Next. Win. 2004;4(1):42-49. X-1, X-2, X-3, X-4.
894 Dyer K. The competition of autistic stereotyped behavior with usual and specially assessed reinforcers. Research in Developmental Disabilities. 1987;8(4):607-626. X-3, X-10. [pmid: 3685547].
895 Dyer K. The effects of preference on spontaneous verbal requests in individuals with autism. Journal of the Association for Persons with Severe Handicaps. Fal. 1989;14(3):184-189. X-10.
896 Dyer K, Christian WP, Luce SC. The role of response delay in improving in the discrimination performance or autistic children. J Appl Behav Anal. Summer. 1982;15(2):231-40. X-10. [pmid: 7118756].
897 Dyer K, Dunlap G, Winterling V. Effects of choice making on the serious problem behaviors of students with severe handicaps. J Appl Behav Anal. Winter. 1990;23(4):515-24. X-3, X-10. [pmid: 2074240].
898 Dyer K, Martino GM, Parvenski T. The River Street Autism Program: a case study of a regional service center behavioral intervention program. Behav Modif. 11. 2006;30(6):925-43. X-4. [pmid: 17050771].
899 Dyer K, Santarcangelo S, Luce SC. Developmental influences in teaching language forms to individuals with developmental disabilities. J Speech Hear Disord. 11. 1987;52(4):335-47. X-10. [pmid: 3669631].
900 Dykens E, Volkmar F, Glick M. Though disorder in high-functioning autistic adults. J Autism Dev Disord. 09. 1991;21(3):291-301. X-1, X-3, X-4, X-10. [pmid: 1938775].
901 Dysken MW, Katz R, Stallone F, et al. Oxiracetam in the treatment of multi-infarct dementia and primary degenerative dementia. J Neuropsychiatry Clin Neurosci. Summer. 1989;1(3):249-52. X-1, X-3, X-4, X-10. [pmid: 2521069].
902 Earles TL, Myles BS. Using behavioral interventions to decrease coprolalia in a student with Tourette’s syndrome and autism: A case study. Focus on Autistic Behavior. 02. 1994;8(6):1-10. X-3, X-10.
903 Eason LJ, White MJ, Newsom C. Generalized reduction of self-stimulatory behavior: An effect of teaching appropriate play to autistic children. Analysis & Intervention in Developmental Disabilities. 1982;2(2–3):157-169. X-10.
904 Eaves LC, Ho HH. The Very Early Identification of Autism: Outcome to Age 4 1/2--5. Journal of Autism and Developmental Disorders. 08. 2004;34(4):367-378. X-4. [pmid: 15449513].
905 Eaves LC, Ho HH. Young Adult Outcome of Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 04. 2008;38(4):739-747. X-1, X-3. [pmid: 17764027].
906 Eberlin M, McConnachie G, Ibel S, et al. Facilitated communication: a failure to replicate the phenomenon. J Autism Dev Disord. 09. 1993;23(3):507-30. X-10. [pmid: 8226584].
907 Edelson SM, Edelson MG, Kerr DC, et al. Behavioral and physiological effects of deep pressure on children with autism: a pilot study evaluating the efficacy of Grandin’s Hug Machine. Am J Occup Ther. 03–04. 1999;53(2):145-52. X-10. [pmid: 10200837].
908 Edelson SM, Rimland B, Berger CL, et al. Evaluation of a mechanical hand-support for facilitated communication. J Autism Dev Disord. 04. 1998;28(2):153-7. X-3, X-10. [pmid: 9586777].
909 Edgerton CL. The effect of improvisational music therapy on the communicative behaviors of autistic children. Journal of Music Therapy. Spr. 1994;31(1):31-62. X-1, X-3, X-4, X-10.
910 Egan PJ, Zlomke LC, Bush BR. Utilizing functional assessment, behavioral consultation and videotape review of treatment to reduce aggression: A case study. Special Services in the Schools. 1993;7(1):27-37. X-10.
911 Egel AL. The effects of constant vs varied reinforcer presentation on responding by autistic children. J Exp Child Psychol. 12. 1980;30(3):455-63. X-10. [pmid: 7205141].
912 Egel AL. Reinforcer variation: Implications for motivating developmentally disabled children. Journal of Applied Behavior Analysis. Fal. 1981;14(3):345-350. X-10. [pmid: 7298543].
913 Egel AL, Richman GS, Koegel RL. Normal peer models and autistic children’s learning. J Appl Behav Anal. Spring. 1981;14(1):3-12. X-3, X-10. [pmid: 7216930].
914 Ehrt U, Bronnick K, De Deyn PP, et al. Subthreshold depression in patients with Parkinson’s disease and dementia--clinical and demographic correlates. Int J Geriatr Psychiatry. 10. 2007;22(10):980-5. X-1, X-3, X-4. [pmid: 17393542].
915 Eide BL, Eide FF. The mislabeled child. New Atlantis. Spring. 2006;12:46-59. X-1, X-2, X-3, X-4. [pmid: 16832954].
916 Eikeseth S. Outcome of comprehensive psycho-educational interventions for young children with autism. Res Dev Disabil. 01–02. 2009;30(1):158-78. X-1, X-2, X-3, X-4. [pmid: 18385012].
917 Eikeseth S, Jahr E. The UCLA reading and writing program: an evaluation of the beginning stages. Res Dev Disabil. 07–08. 2001;22(4):289-307. X-3. [pmid: 11523953].
918 Eikeseth S, Lovaas OI. The autistic label and its potentially detrimental effect on the child’s treatment. J Behav Ther Exp Psychiatry. 09. 1992;23(3):151-7. X-1, X-3, X-4, X-10. [pmid: 1487532].
919 Eisermann MM, DeLaRaillere A, Dellatolas G, et al. Infantile spasms in Down syndrome--effects of delayed anticonvulsive treatment. Epilepsy Res. 06–07. 2003;55(1–2):21-7. X-1, X-3, X-4. [pmid: 12948613].
920 Ekman G, Miranda-Linne F, Gillberg C, et al. Fenfluramine treatment of twenty children with autism. J Autism Dev Disord. 12. 1989;19(4):511-32. X-10. [pmid: 2606882].
921 Elchaar GM, Maisch NM, Augusto LM, et al. Efficacy and safety of naltrexone use in pediatric patients with autistic disorder. Ann Pharmacother. 06. 2006;40(6):1086-95. X-1, X-2, X-3, X-4. [pmid: 16735648].
922 Elder J, Kneipp S. Faculty receive million dollar NIH grants to continue their research. Fla Nurse. 12. 2005;53(4):28. X-1, X-2, X-3, X-4.
923 Elder JH. Beliefs held by parents of autistic children. J Child Adolesc Psychiatr Nurs. 01–03. 1994;7(1):9-16. X-1, X-2, X-3, X-4, X-10. [pmid: 8000776].
924 Elder JH. In-home communication intervention training for parents of multiply handicapped children. Sch Inq Nurs Pract. Spring. 1995;9(1):71-92. discussion 93–5. X-3, X-10. [pmid: 7777745].
925 Elder JH. A follow-up study of beliefs held by parents of children with pervasive developmental delay. J Child Adolesc Psychiatr Nurs. 04–06. 2001;14(2):55-60. X-4. [pmid: 11883624].
926 Elder JH, D’Alessandro T. Supporting families of children with autism spectrum disorders: questions parents ask and what nurses need to know. Pediatr Nurs. 07–08. 2009;35(4):240-5. 253. X-1, X-2, X-3, X-4. [pmid: 19785304].
927 Elder JH, Valcante G, Groce S, et al. Social interactions of children with autism in father-child and mother-child play sessions. Pediatr Nurs. 11–12. 2002;28(6):573-8. 581. X-4. [pmid: 12593342].
928 Elder JH, Valcante G, Won D, et al. Effects of in-home training for culturally diverse fathers of children with autism. Issues Ment Health Nurs. 04–05. 2003;24(3):273-95. X-3. [pmid: 12623686].
929 Elder LM, Caterino LC, Chao J, et al. The Efficacy of Social Skills Treatment for Children with Asperger Syndrome. Education and Treatment of Children. 11. 2006;29(4):635-663. X-1, X-2, X-3, X-4.
930 Eldevik S, Hastings RP, Hughes JC, et al. Meta-analysis of Early Intensive Behavioral Intervention for children with autism. J Clin Child Adolesc Psychol. 05. 2009;38(3):439-50. X-2. [pmid: 19437303].
931 Eldevik S, Jahr E, Eikeseth S, et al. Cognitive and adaptive behavior outcomes of behavioral intervention for young children with intellectual disability. Behav Modif. 01. 2010;34(1):16-34. X-1, X-3, X-4. [pmid: 20051523].
932 Elfert M, Mirenda P. The experiences of behavior interventionists who work with children with autism in families’ homes. Autism. 11. 2006;10(6):577-91. X-1, X-3, X-4. [pmid: 17088274].
933 el-Ghoroury NH, Romanczyk RG. Play interactions of family members towards children with autism. J Autism Dev Disord. 06. 1999;29(3):249-58. X-4, X-10. [pmid: 10425587].
934 Elia M, Ferri R, Musumeci SA, et al. Sleep in subjects with autistic disorder: a neurophysiological and psychological study. Brain Dev. 03. 2000;22(2):88-92. X-4. [pmid: 10722958].
935 Eliasoph E, Donnellan AM. A group therapy program for individuals identified as autistic who are without speech and use facilitated communication. International Journal of Group Psychotherapy. 10. 1995;45(4):549-560. X-10. [pmid: 7558507].
936 El-Leithy S, Webb Z. A matter of distinction. Health Serv J. 03. 12. 1998;108(5595):32-3. X-10.
937 Ellenberg SS. Safety considerations for new vaccine development. Pharmacoepidemiol Drug Saf. 08–09. 2001;10(5):411-5. X-1, X-2, X-3, X-4. [pmid: 11802587].
938 Elliott RO Jr, Dobbin AR, Rose GD, et al. Vigorous, aerobic exercise versus general motor training activities: effects on maladaptive and stereotypic behaviors of adults with both autism and mental retardation. J Autism Dev Disord. 10. 1994;24(5):565-76. X-1, X-3, X-10. [pmid: 7814306].
939 Elliott RO Jr, Hall K, Soper HV. Analog language teaching versus natural language teaching: generalization and retention of language learning for adults with autism and mental retardation. J Autism Dev Disord. 12. 1991;21(4):433-47. X-1, X-3, X-10. [pmid: 1778959].
940 Ellis CR, Lutz RE, Schaefer GB, et al. Physician Collaboration Involving Students with Autism Spectrum Disorders. Psychology in the Schools. 09. 2007;44(7):737-747. X-2, X-3, X-4.
941 Ellis EM, Ala’i-Rosales SS, Glenn SS, et al. The effects of graduated exposure, modeling, and contingent social attention on tolerance to skin care products with two children with autism. Research in Developmental Disabilities. 11–12. 2006;27(6):585-598. X-3. [pmid: 16242911].
942 Emanuel L. Facing the damage together: Some reflections arising from the treatment in psychotherapy of a severely mentally handicapped child. Journal of Child Psychotherapy. 08. 1997;23(2):279-302. X-3, X-10.
943 Emerson E, Hatton C. Mental health of children and adolescents with intellectual disabilities in Britain. Br J Psychiatry. 12. 2007;191:493-9. X-4. [pmid: 18055952].
944 Endicott K, Higbee TS. Contriving motivating operations to evoke mands for information in preschoolers with autism. Research in Autism Spectrum Disorders. 07–09. 2007;1(3):210-217. X-3.
945 English CL, Anderson CM. Effects of familiar versus unfamiliar therapists on responding in the analog functional analysis. Res Dev Disabil. 01–02. 2004;25(1):39-55. X-3. [pmid: 14733975].
946 Engstrom I, Ekstrom L, Emilsson B. Psychosocial functioning in a group of Swedish adults with Asperger syndrome or high-functioning autism. Autism. 03. 2003;7(1):99-110. X-1, X-3, X-4. [pmid: 12638767].
947 Epp KM. Outcome-Based Evaluation of a Social Skills Program Using Art Therapy and Group Therapy for Children on the Autism Spectrum. Children & Schools. 2008;30(1):27-36. X-1.
948 Epperson CN, McDougle CJ, Anand A, et al. Lithium augmentation of fluvoxamine in autistic disorder: A case report. Journal of Child and Adolescent Psychopharmacology. Fal. 1994;4(3):201-207. X-1, X-3, X-10.
949 Epstein LJ, Taubman MT, Lovaas OI. Changes in self-stimulatory behaviors with treatment. J Abnorm Child Psychol. 06. 1985;13(2):281-93. X-3, X-10. [pmid: 4008756].
950 Epstein N. A residence for autistic and schizophrenic adolescents. Soc Casework. 04. 1982;63(4):209-14. X-10. [pmid: 10318544].
951 Erba HW. Early intervention programs for children with autism: conceptual frameworks for implementation. Am J Orthopsychiatry. 01. 2000;70(1):82-94. X-1, X-2, X-3, X-4. [pmid: 10702853].
952 Erickson CA, Mullett JE, McDougle CJ. Open-Label Memantine in Fragile X Syndrome. Journal of Autism and Developmental Disorders. 12. 2009;39(12):1629-1635. X-1, X-3.
953 Erickson CA, Posey DJ, Stigler KA, et al. A retrospective study of memantine in children and adolescents with pervasive developmental disorders. Psychopharmacology. Special Issue: Pediatric psychopharmacology: Mood, anxiety and disruptive behavior/pervasive developmental disorders. 03. 2007;191(1):141-147. X-1.
954 Erickson CA, Stigler KA, Corkins MR, et al. Gastrointestinal Factors in Autistic Disorder: A Critical Review. Journal of Autism and Developmental Disorders. 12. 2005;35(6):713-727. X-1, X-2, X-3, X-4. [pmid: 16267642].
955 Ericson MB, Sandberg C, Gudmundson F, et al. Fluorescence contrast and threshold limit: implications for photodynamic diagnosis of basal cell carcinoma. J Photochem Photobiol B. 02. 2003;69(2):121-7. X-1, X-2, X-3, X-4. [pmid: 12633984].
956 Ernst M, Devi L, Silva RR, et al. Plasma beta-endorphin levels, naltrexone, and haloperidol in autistic children. Psychopharmacol Bull. 1993;29(2):221-7. X-4, X-10. [pmid: 8290669].
957 Ernst M, Magee HJ, Gonzalez NM, et al. Pimozide in autistic children. Psychopharmacol Bull. 1992;28(2):187-91. X-10. [pmid: 1513923].
958 Erwin R, Van Lancker D, Guthrie D, et al. P3 responses to prosodic stimuli in adult autistic subjects. Electroencephalogr Clin Neurophysiol. 11–12. 1991;80(6):561-71. X-1, X-4, X-10. [pmid: 1720733].
959 Esbensen AJ, Greenberg JS, Seltzer MM, et al. A longitudinal investigation of psychotropic and non-psychotropic medication use among adolescents and adults with autism spectrum disorders. J Autism Dev Disord. 09. 2009;39(9):1339-49. X-1, X-2, X-3, X-4. [pmid: 19434487].
960 Esbenshade PH, Rosales-Ruiz Js. Programming common stimuli to promote generalized question-asking: A case demonstration in a child with autism. Journal of Positive Behavior Interventions. Fal. 2001;3(4):199-210. X-3, X-4.
961 Esch BE, Carr JE. Secretin as a Treatment for Autism: A Review of the Evidence. Journal of Autism and Developmental Disorders. 10. 2004;34(5):543-556. X-1, X-2, X-3, X-4. [pmid: 15628608].
962 Esch BE, Carr JE, Grow LL. Evaluation of an Enhanced Stimulus-Stimulus Pairing Procedure to Increase Early Vocalizations of Children with Autism. Journal of Applied Behavior Analysis. Sum. 2009;42(2):225-241. X-3. [pmid: 19949511].
963 Esch BE, Carr JE, Michael J. Evaluating Stimulus-Stimulus Pairing and Direct Reinforcement in the Establishment of an Echoic Repertoire of Children Diagnosed with Autism, Analysis of Verbal Behavior Journal Citation. 2005;21:43-58. Publisher: Association for Behavior Analysis International. 1219 South Park Street, Kalamazoo, MI 49001. Tel: 269-492-9310; Fax: 269-492-9316; e-mail: mail@abainternational.org; Web site: http://www.abainternational.org/TAVB.asp. 2005 Pub Types: Journal Articles; Reports - Research. X-3.
964 Escribano Hernandez A, Hernandez Corral T, Ruiz-Martin E, et al. Results of a dental care protocol for mentally handicapped patients set in a primary health care area in Spain. Med Oral Patol Oral Cir Bucal. 12. 2007;12(7):E492-5. X-1, X-3, X-4. [pmid: 17978772].
965 Eskes GA, Bryson SE, McCormick TA. Comprehension of concrete and abstract words in autistic children. J Autism Dev Disord. 03. 1990;20(1):61-73. X-4, X-10. [pmid: 2324056].
966 Estes A, Munson J, Dawson G, et al. Parenting stress and psychological functioning among mothers of preschool children with autism and developmental delay. Autism. 07. 2009;13(4):375-87. X-4. [pmid: 19535467].
967 Estes AM, Dawson G, Sterling L, et al. Level of intellectual functioning predicts patterns of associated symptoms in school-age children with autism spectrum disorder. Am J Ment Retard. 11. 2007;112(6):439-49. X-4. [pmid: 17963435].
968 Eto I, Bandy MD, Butterworth CE. Plasma and urinary levels of biopterin, neopterin, and related pterins and plasma levels of folate in infantile autism. Journal of Autism and Developmental Disorders. 06. 1992;22(2):295-308. X-4, X-10. [pmid: 1624410].
969 Evans C, Dunstan RH, Rothkirch T, et al. Altered amino acid excretion in children with autism. Nutr Neurosci. 02. 2008;11(1):9-17. X-4. [pmid: 18510798].
970 Evans G. Update on vaccine liability in the United States: presentation at the National Vaccine Program Office Workshop on strengthening the supply of routinely recommended vaccines in the United States, 12 February 2002. Clin Infect Dis. 03. 1. 2006;42(Suppl 3):S130-7. X-1, X-2, X-3, X-4. [pmid: 16447135].
971 Evans M, Stoddart H, Condon L, et al. Parents’ perspectives on the MMR immunisation: a focus group study. Br J Gen Pract. 11. 2001;51(472):904-10. X-1, X-3, X-4. [pmid: 11761204].
972 Evans MD, Patrocinio HJ, Souhami L, et al. Dosimetry of hip irradiation for the prevention of heterotopic bone formation after arthroplasty. Int J Radiat Oncol Biol Phys. 03. 15. 1999;43(5):1161-5. X-1, X-2, X-3, X-4, X-10. [pmid: 10192368].
973 Evers S. Music therapy in the treatment of autistic children. Medico-sociological data from the Federal Republic of Germany. Acta Paedopsychiatr. 1992;55(3):157-8. X-1, X-3, X-4, X-10. [pmid: 1414349].
974 Faber S. International adoption: A four-year-old child with unusual behaviors adopted at six months of age: Dr. Scott Faber. Journal of Developmental & Behavioral Pediatrics. 02. 2003;24(1):64-65. X-3.
975 Fabian KJ. Deep-feeling development gives autistics abstractions: when a young person has no abstractions, his or her thoughts or behaviors frequently seem autistic. Med Hypotheses. 2005;65(4):694-8. X-1, X-2, X-3, X-4. [pmid: 16019156].
976 Fabrizio MA, Schirmer K, Vu E, et al. Analog Analysis of Two Variables Related to the Joint Attention of a Toddler with Autism. Journal of Precision Teaching & Celeration. Spr. 2003;19(1):41-44. X-3.
977 Factor DC, Perry A, Freeman N. Stress, social support, and respite care use in families with autistic children. J Autism Dev Disord. 03. 1990;20(1):139-46. X-10. [pmid: 2324052].
978 Fahlvik-Planefeldt C, Herrstrom P. Dental care of autistic children within the non-specialized Public Dental Service. Swed Dent J. 2001;25(3):113-8. X-4. [pmid: 11813447].
979 Faja S, Aylward E, Bernier R, et al. Becoming a face expert: a computerized face-training program for high-functioning individuals with autism spectrum disorders. Dev Neuropsychol. 2008;33(1):1-24. X-1, X-3, X-4. [pmid: 18443967].
980 Falcomata TS, Roane HS, Hovanetz AN, et al. An evaluation of response cost in the treatment of inappropriate vocalizations maintained by automatic reinforcement. Journal of Applied Behavior Analysis. Spr. 2004;37(1):83-87. X-1, X-3, X-4. [pmid: 15154219].
981 Falcomata TS, Roane HS, Pabico RR. Unintentional stimulus control during the treatment of pica displayed by a young man with autism. Research in Autism Spectrum Disorders. 10–12. 2007;1(4):350-359. X-3.
982 Fallon J. Could one of the most widely prescribed antibiotics amoxicillin/clavulanate “augmentin” be a risk factor for autism?. Med Hypotheses. 2005;64(2):312-5. X-4. [pmid: 15607562].
983 Fankhauser MP, Karumanchi VC, German ML, et al. A double-blind, placebo-controlled study of the efficacy of transdermal clonidine in autism. J Clin Psychiatry. 03. 1992;53(3):77-82. X-3, X-10. [pmid: 1548248].
984 Fantuzzo JW, Smith C. Linking community-based treatment settings for a disturbed autistic child. Education & Training of the Mentally Retarded. 04. 1984;19(2):102-107. X-3, X-10.
985 Fantuzzo JW, Smith CS. Programmed generalization of dress efficiency across settings for a severely disturbed, autistic child. Psychological Reports. 12. 1983;53(3, Pt 1):871-879. X-3, X-10. [pmid: 6657839].
986 Farley MA, McMahon WM, Fombonne E, et al. Twenty-year outcome for individuals with autism and average or near-average cognitive abilities. Autism Res. 04. 2009;2(2):109-18. X-1, X-4. [pmid: 19455645].
987 Farmer JE, Clark MJ. Identification and evaluation of Missouri’s children with autism spectrum disorders: promoting a rapid response. Mo Med. 09–10. 2008;105(5):384-9. X-1, X-2, X-3, X-4. [pmid: 18807359].
988 Farmer-Dougan V. Increasing requests by adults with developmental disabilities using incidental teaching by peers. J Appl Behav Anal. Fall. 1994;27(3):533-44. X-1, X-10. [pmid: 7928794].
989 Farrington CP, Miller E, Taylor B. MMR and autism: further evidence against a causal association. Vaccine. 06. 14. 2001;19(27):3632-5. X-4. [pmid: 11395196].
990 Fatemi SH, Realmuto GM, Khan L, et al. Fluoxetine in treatment of adolescent patients with autism: a longitudinal open trial. J Autism Dev Disord. 08. 1998;28(4):303-7. X-3, X-10. [pmid: 9711486].
991 Fava L, Strauss K. Multi-Sensory Rooms: Comparing Effects of the Snoezelen and the Stimulus Preference Environment on the Behavior of Adults with Profound Mental Retardation. Research in Developmental Disabilities: A Multidisciplinary Journal. 01–02. 2010;31(1):160-171. X-1, X-3.
992 Fazzi E, Rossi M, Signorini S, et al. Leber’s Congenital Amaurosis: Is There an Autistic Component?. Developmental Medicine & Child Neurology. 07. 2007;49(7):503-507. X-4. [pmid: 17593121].
993 Felce D, Kerr M, Hastings RP. A general practice-based study of the relationship between indicators of mental illness and challenging behaviour among adults with intellectual disabilities. J Intellect Disabil Res. 03. 2009;53(3):243-54. X-1, X-4. [pmid: 19017165].
994 Feldman HM, Kolmen BK, Gonzaga AM. Naltrexone and communication skills in young children with autism. J Am Acad Child Adolesc Psychiatry. 05. 1999;38(5):587-93. X-10. [pmid: 10230191].
995 Feldman MA, Werner SE. Collateral effects of behavioral parent training on families of children with developmental disabilities and behavior disorders. Behavioral Interventions. 04–06. 2002;17(2):75-83. X-1, X-4.
996 Feng H, Lo Y-y, Tsai S, et al. The Effects of Theory-of-Mind and Social Skill Training on the Social Competence of a Sixth-Grade Student with Autism. Journal of Positive Behavior Interventions. 2008;10(4):228-242. X-3.
997 Fenske EC, Zalenski S, Krantz PJ, et al. Age at intervention and treatment outcome for autistic children in a comprehensive intervention program. Analysis & Intervention in Developmental Disabilities. Special Issue: Early intervention. 1985;5(1–2):49-58. X-10.
998 Ferguson AP, McKinlay IA, Hunt A. Care of adolescents with severe learning disability from tuberous sclerosis. Dev Med Child Neurol. 04. 2002;44(4):256-62. X-1, X-4. [pmid: 11995894].
999 Ferguson H, Myles BS, Hagiwara T. Using a Personal Digital Assistant to Enhance the Independence of an Adolescent with Asperger Syndrome. Education and Training in Developmental Disabilities. 03. 2005;40(1):60-67. X-1, X-3.
1000 Fernandes FD, Cardoso C, Sassi FC, et al. Language therapy and autism: results of three different models. Pro Fono. 10–12. 2008;20(4):267-72. X-4. [pmid: 19142471].
1001 Fernell E, Gillberg C, von Wendt L. Autistic symptoms in children with infantile hydrocephalus. Acta Paediatr Scand. 04. 1991;80(4):451-7. X-4, X-10. [pmid: 2058395].
1002 Fernell E, Watanabe Y, Adolfsson I, et al. Possible effects of tetrahydrobiopterin treatment in six children with autism--clinical and positron emission tomography data: a pilot study. Dev Med Child Neurol. 05. 1997;39(5):313-8. X-3, X-10. [pmid: 9236697].
1003 Feroz-Nainar C, Roy M. Risperidone and late onset tics. Autism. 05. 2006;10(3):302-7. X-1, X-3. [pmid: 16682400].
1004 Ferrara C, Hill SD. The responsiveness of autistic children to the predictability of social and nonsocial toys. J Autism Dev Disord. 03. 1980;10(1):51-7. X-4, X-10. [pmid: 6927678].
1005 Ferrari M. Effects of praise and reprimand on the topography and probability of occurrence of stereotypies in autistic children. Psychol Rep. 04. 1980;46(2):519-22. X-10. [pmid: 7384356].
1006 Ferrari M, Harris SL. The limits and motivating potential of sensory stimuli as reinforcers for autistic children. J Appl Behav Anal. Fall. 1981;14(3):339-43. X-3, X-10. [pmid: 7298542].
1007 Ferreri SJ, Tamm L, Wier KG. Using Food Aversion to Decrease Severe Pica by a Child with Autism. Behavior Modification. 2006;30(4):456-471. X-3. [pmid: 16723425].
1008 Ferri R, Elia M, Agarwal N, et al. The mismatch negativity and the P3a components of the auditory event-related potentials in autistic low-functioning subjects. Clin Neurophysiol. 09. 2003;114(9):1671-80. X-4. [pmid: 12948796].
1009 Fertel-Daly D, Bedell G, Hinojosa J. Effects of a weighted vest on attention to task and self-stimulatory behaviors in preschoolers with pervasive developmental disorders. Am J Occup Ther. 11–12. 2001;55(6):629-40. X-3. [pmid: 12959227].
1010 Fido A, Al-Saad S. Olanzapine in the treatment of behavioral problems associated with autism: an open-label trial in Kuwait. Med Princ Pract. 2008;17(5):415-8. X-1, X-3. [pmid: 18685284].
1011 Field T, Lasko D, Mundy P, et al. Brief report: autistic children’s attentiveness and responsivity improve after touch therapy. J Autism Dev Disord. 06. 1997;27(3):333-8. X-10. [pmid: 9229263].
1012 Fienup DM, Doepke K. Evaluation of a Changing Criterion Intervention to Increase Fluent Responding with an Elementary Age Student with Autism. International Journal of Behavioral Consultation and Therapy. 2008;4(3):297-303. X-3.
1013 Filipo R, Bosco E, Mancini P, et al. Cochlear implants in special cases: deafness in the presence of disabilities and/or associated problems. Acta Otolaryngol Suppl. 05. 2004;(552):74-80. X-1, X-3, X-4.
1014 Findling RL. Paediatric psychopharmacology: closing the gap between science and practice. Expert Opin Pharmacother. 04. 2001;2(4):523-5. X-1, X-2, X-3. [pmid: 11336602].
1015 Findling RL. Pharmacologic treatment of behavioral symptoms in autism and pervasive developmental disorders. J Clin Psychiatry. 2005;66(Suppl 10):26-31. X-1, X-2, X-3, X-4.
1016 Findling RL, Aman MG, Eerdekens M, et al. Long-term, open-label study of risperidone in children with severe disruptive behaviors and below-average IQ. Am J Psychiatry. 04. 2004;161(4):677-84. X-1. [pmid: 15056514].
1017 Findling RL, Kauffman RE, Sallee FR, et al. Tolerability and pharmacokinetics of aripiprazole in children and adolescents with psychiatric disorders: an open-label, dose-escalation study. J Clin Psychopharmacol. 08. 2008;28(4):441-6. X-1, X-3, X-4. [pmid: 18626272].
1018 Findling RL, Kusumakar V, Daneman D, et al. Prolactin levels during long-term risperidone treatment in children and adolescents. J Clin Psychiatry. 11. 2003;64(11):1362-9. X-1, X-4. [pmid: 14658952].
1019 Findling RL, Maxwell K, Scotese-Wojtila L, et al. High-dose pyridoxine and magnesium administration in children with autistic disorder: an absence of salutary effects in a double-blind, placebo-controlled study. J Autism Dev Disord. 08. 1997;27(4):467-78. X-10. [pmid: 9261669].
1020 Findling RL, Maxwell K, Wiznitzer M. An open clinical trial of risperidone monotherapy in young children with autistic disorder. Psychopharmacol Bull. 1997;33(1):155-9. X-3, X-10. [pmid: 9133768].
1021 Findling RL, McNamara NK, Branicky LA, et al. A double-blind pilot study of risperidone in the treatment of conduct disorder. J Am Acad Child Adolesc Psychiatry. 04. 2000;39(4):509-16. X-1, X-3, X-4. [pmid: 10761354].
1022 Findling RL, McNamara NK, Gracious BL, et al. Quetiapine in nine youths with autistic disorder. J Child Adolesc Psychopharmacol. Summer. 2004;14(2):287-94. X-3. [pmid: 15319025].
1023 Fine P, McGee JJ, Paden S. Autism in Nebraska: identification and treatment. Nebr Med J. 06. 1981;66(6):127-9. X-10.
1024 Finegold SM. Therapy and epidemiology of autism--clostridial spores as key elements. Med Hypotheses. 2008;70(3):508-11. X-2, X-4. [pmid: 17904761].
1025 Finegold SM, Vaisanen ML, Molitoris DR, et al. Cetobacterium somerae sp. nov. from human feces and emended description of the genus Cetobacterium. Syst Appl Microbiol. 06. 2003;26(2):177-81. X-1, X-3, X-4. [pmid: 12866843].
1026 Finke EH, McNaughton DB, Drager KD. “All children can and should have the opportunity to learn”: general education teachers’ perspectives on including children with autism spectrum disorder who require AAC. Augment Altern Commun. 06. 2009;25(2):110-22. X-1, X-3, X-4. [pmid: 19444682].
1027 Finkel AS, Williams RL. A comparison of textual and echoic prompts on the acquisition of intraverbal behavior in a six-year-old boy with autism. Analysis of Verbal Behavior. 2001;18:61-70. X-3.
1028 Firbank MJ, Burn DJ, McKeith IG, et al. Longitudinal study of cerebral blood flow SPECT in Parkinson’s disease with dementia, and dementia with Lewy bodies. Int J Geriatr Psychiatry. 08. 2005;20(8):776-82. X-1, X-4. [pmid: 16035122].
1029 Firth G, Elford H, Leeming C, et al. Intensive Interaction as a Novel Approach in Social Care: Care Staff’s Views on the Practice Change Process. Journal of Applied Research in Intellectual Disabilities. 01. 2008;21(1):58-69. X-1, X-3, X-4.
1030 Firth H, Grimes A, Poppleton H, et al. Assessment of parents’ concerns and evaluation of outcomes. J Public Health Med. 12. 2000;22(4):473-8. X-1, X-4. [pmid: 11192274].
1031 Fisch GS, Cohen IL, Gross AC, et al. Folic acid treatment of fragile X males: a further study. Am J Med Genet. 05–06. 1988;30(1–2):393-9. X-1, X-4, X-10. [pmid: 3052065].
1032 Fischhof PK. Divergent neuroprotective effects of nimodipine in PDD and MID provide indirect evidence of disturbances in Ca2+ homeostasis in dementia. Methods Find Exp Clin Pharmacol. 10. 1993;15(8):549-55. X-1, X-4, X-10. [pmid: 7794292].
1033 Fish LH, Moore AL, Morgan B, et al. Evaluation of admission blood glucose levels in the intensive care unit. Endocr Pract. 11–12. 2007;13(7):705-10. X-1, X-4. [pmid: 18194925].
1034 Fisher N, Happe F. A training study of theory of mind and executive function in children with autistic spectrum disorders. J Autism Dev Disord. 12. 2005;35(6):757-71. X-1, X-3. [pmid: 16283087].
1035 Fisher SM. A Case Study of an Autistic Child: A Reappraisal. The Annual of Psychoanalysis. 2000;28:47-61. X-1, X-3.
1036 Fisher W, Burd L, Kerbeshian J. Markers for improvement in children with pervasive developmental disorders. J Ment Defic Res. 10. 1988;32(Pt 5):357-69. X-4, X-10. [pmid: 3199430].
1037 Fisher W, Kerbeshian J, Burd L. A treatable language disorder: pharmacological treatment of pervasive developmental disorder. J Dev Behav Pediatr. 04. 1986;7(2):73-6. X-3, X-10. [pmid: 3700663].
1038 Fisher WW, Adelinis JD, Volkert VM, et al. Assessing P for Positive and Negative Reinforcement during Treatment of Destructive Behavior with Functional Communication Training. Research in Developmental Disabilities: A Multidisciplinary Journal. 03–04. 2005;26(2):153-168. X-3, X-4.
1039 Fisher WW, Lindauer SE, Alterson CJ, et al. Assessment and treatment of destructive behavior maintained by stereotypic object manipulation. Journal of Applied Behavior Analysis. Win. 1998;31(4):513-527. X-1, X-3, X-10. [pmid: 9891391].
1040 Fisher WW, Thompson RH, Hagopian LP, et al. Facilitating Tolerance of Delayed Reinforcement during Functional Communication Training. Behavior Modification Journal Citation. 01. 2000;24(1):3-29. Publisher:. 2000 Pub Types: Journal Articles; Reports - Research. X-3.
1041 Fisher-Polites C. “PBS” Spelled “Friends”. Journal of Positive Behavior Interventions. 2004;6(3):178-180. X-2, X-3, X-4.
1042 Fisman S, Steele M, Short J, et al. Case study: Anorexia nervosa and autistic disorder in an adolescent girl. Journal of the American Academy of Child & Adolescent Psychiatry. 07. 1996;35(7):937-940. X-1, X-3, X-10. [pmid: 8768355].
1043 Fisman S, Wolf L. The handicapped child: psychological effects of parental, marital, and sibling relationships. Psychiatr Clin North Am. 03. 1991;14(1):199-217. X-1, X-2, X-3, X-4, X-10. [pmid: 1828565].
1044 Fitzpatrick M. The end of the road for the campaign against MMR. Br J Gen Pract. 08. 2007;57(541):679. X-1, X-2, X-3,X-4. [pmid: 17688775].
1045 Fitzpatrick M. Treating autism appropriately. Br J Gen Pract. 05. 2009;59(562):379. X-1, X-2, X-3, X-4. [pmid: 19401028].
1046 Flagg EJ, Cardy JE, Roberts W, et al. Language lateralization development in children with autism: insights from the late field magnetoencephalogram. Neurosci Lett. 09. 30. 2005;386(2):82-7. X-4. [pmid: 16046066].
1047 Floyd EF, McIntosh DE. Current Practice in Psychopharmacology for Children and Adolescents with Autism Spectrum Disorders. Psychology in the Schools. 11. 2009;46(9):905-909. X-1, X-2, X-3, X-4.
1048 Fodstad JC, Matson JL. A comparison of feeding and mealtime problems in adults with intellectual disabilities with and without autism. Journal of Developmental and Physical Disabilities. 2008;20(6):4. X-1, X-3, X-4.
1049 Foley BE, Staples AH. Developing augmentative and alternative communication (AAC) and literacy interventions in a supported employment setting. Topics in Language Disorders. 10–12. 2003;23(4):325-343. X-1, X-3.
1050 Fombonne E. Diagnostic assessment in a sample of autistic and developmentally impaired adolescents. J Autism Dev Disord. 12. 1992;22(4):563-81. X-4, X-10. [pmid: 1483977].
1051 Fombonne E, Achard S. The Vineland Adaptive Behavior Scale in a sample of normal French Children: a research note. J Child Psychol Psychiatry. 09. 1993;34(6):1051-8. X-1, X-4, X-10. [pmid: 8408369].
1052 Fombonne E, Chakrabarti S. No evidence for a new variant of measles-mumps-rubella-induced autism. Pediatrics. 10. 2001;108(4):E58. X-1, X-4. [pmid: 11581466].
1053 Fombonne E, Talan I, Bouchard F, et al. A follow-up study of childhood psychosis. Acta Paedopsychiatr. 1989;52(1):12-25. X-10. [pmid: 2626958].
1054 Fombonne E, Zakarian R, Bennett A, et al. Pervasive developmental disorders in Montreal, Quebec, Canada: prevalence and links with immunizations. Pediatrics. 07. 2006;118(1):e139-50. X-4. [pmid: 16818529].
1055 Fong PL. Cognitive appraisals in high- and low-stress mothers of adolescents with autism. J Consult Clin Psychol. 06. 1991;59(3):471-4. X-1, X-4, X-10. [pmid: 2071734].
1056 Fonseca VRJRM. The Autistic Dialogic Style: A Case of Asperger’s Syndrome. Journal of Child Psychotherapy. 12. 2009;35(3):250-261. X-3, X-4.
1057 Fontenelle LF, Mendlowicz MV, de Menezes GB, et al. Asperger Syndrome, Obsessive-Compulsive Disorder, and Major Depression in a Patient with 45,X/46,XY Mosaicism. Psychopathology. 05–06. 2004;37(3):105-109. X-2, X-3, X-4. [pmid: 15153741].
1058 Forbes J, Welbon H. Teacher/therapist collaboration: a Scottish higher education institution development. Int J Lang Commun Disord. 2001;36(Suppl):417-22. X-1, X-3, X-4. [pmid: 11340824].
1059 Forsberg KA, Bjorkman T, Sandman PO, et al. Physical health--a cluster randomized controlled lifestyle intervention among persons with a psychiatric disability and their staff. Nord J Psychiatry. 2008;62(6):486-95. X-1, X-3, X-4. [pmid: 18843564].
1060 Forsyth R, Colver A, Alvanides S, et al. Participation of young severely disabled children is influenced by their intrinsic impairments and environment. Dev Med Child Neurol. 05. 2007;49(5):345-9. X-4. [pmid: 17489807].
1061 Fox MH, Foster CH, Zito JM. Building pharmacoepidemiological capacity to monitor psychotropic drug use among children enrolled in Medicaid. Am J Med Qual. 07–08. 2000;15(4):126-36. X-4. [pmid: 10948784].
1062 Foxton JM, Stewart ME, Barnard L, et al. Absence of auditory ‘global interference’ in autism. Brain. 12. 2003;126(Pt 12):2703-9. X-4. [pmid: 12937074].
1063 Foxx RM, Faw GD. Long-term follow-up of echolalia and question answering. Journal of Applied Behavior Analysis. Fal. 1990;23(3):387-396. X-1, X-3, X-10. [pmid: 2249974].
1064 Foxx RM, Garito J. The long term successful treatment of the very severe behaviors of a preadolescent with autism. Behavioral Interventions. Special Issue: The treatment and assessment of the severe behavior of individuals with autism and developmental disabilities. 02. 2007;22(1):69-82. X-3.
1065 Foxx RM, Schreck KA, Garito J, et al. Replacing the Echolalia of Children With Autism With Functional Use of Verbal Labeling. Journal of Developmental and Physical Disabilities. 12. 2004;16(4):307-320. X-3.
1066 Fragala-Pinkham M, Haley SM, O’Neil ME. Group aquatic aerobic exercise for children with disabilities. Dev Med Child Neurol. 11. 2008;50(11):822-7. X-3. [pmid: 19046177].
1067 Francescon P, Cora S, Cavedon C, et al. Use of a new type of radiochromic film, a new parallel-plate micro-chamber, MOSFETs, and TLD 800 microcubes in the dosimetry of small beams. Med Phys. 04. 1998;25(4):503-11. X-1, X-3, X-4, X-10. [pmid: 9571618].
1068 Franch NJP. Transference and countertransference in the analysis of a child with autistic nuclei. International Journal of Psycho-Analysis. 08. 1996;77(4):773-786. X-3, X-10. [pmid: 8876335].
1069 Francis P, Mellor D, Firth L. Techniques and recommendations for the inclusion of users with autism in the design of assistive technologies. Assist Technol. Summer. 2009;21(2):57-68. X-1, X-3, X-4. [pmid: 19715250].
1070 Francisco MT, Borrero JC, Sy JR. Evaluation of absolute and relative reinforcer value using progressive-ratio schedules. J Appl Behav Anal. Summer. 2008;41(2):189-202. X-3. [pmid: 18595283].
1071 Franco JH, Lang RL, O’Reilly MF, et al. Functional Analysis and Treatment of Inappropriate Vocalizations Using a Speech-Generating Device for a Child with Autism. Focus on Autism and Other Developmental Disabilities. 2009;24(3):146-155. X-3.
1072 Frankel F, Myatt R, Feinberg D. Parent-assisted friendship training for children with autism spectrum disorders: effects of psychotropic medication. Child Psychiatry Hum Dev. 04. 2007;37(4):337-46. X-3. [pmid: 17406973].
1073 Frankland PW, Wang Y, Rosner B, et al. Sensorimotor gating abnormalities in young males with fragile X syndrome and Fmr1-knockout mice. Mol Psychiatry. 04. 2004;9(4):417-25. X-4. [pmid: 14981523].
1074 Frazier JA, Meyer MC, Biederman J, et al. Risperidone treatment for juvenile bipolar disorder: a retrospective chart review. J Am Acad Child Adolesc Psychiatry. 08. 1999;38(8):960-5. X-1, X-4, X-10. [pmid: 10434487].
1075 Frea WD. Reducing stereotypic behavior by teaching orienting responses to environmental stimuli. Journal of the Association for Persons with Severe Handicaps. Spr. 1997;22(1):28-35. X-1, X-3, X-10.
1076 Frea WD, Arnold CL, Vittimberga GL. A demonstration of the effects of augmentative communication on the extreme aggressive behavior of a child with autism within an integrated preschool setting. Journal of Positive Behavior Interventions. Fal. 2001;3(4):194-198. X-3.
1077 Freeman BJ, Del’Homme M, Guthrie D, et al. Vineland Adaptive Behavior Scale scores as a function of age and initial IQ in 210 autistic children. J Autism Dev Disord. 10. 1999;29(5):379-84. X-4, X-10. [pmid: 10587884].
1078 Freeman BJ, Ritvo ER. The syndrome of autism: establishing the diagnosis and principles of management. Pediatr Ann. 04. 1984;13(4):284-90. 294. 6. X-2, X-10. [pmid: 6203089].
1079 Freeman EW, Rickels K, Sondheimer SJ. Fluvoxamine for premenstrual dysphoric disorder: a pilot study. J Clin Psychiatry. 1996;57(Suppl 8):56-9. discussion 60. X-1, X-4, X-10. [pmid: 8698682].
1080 Freeman KA, Piazza CC. Combining stimulus fading, reinforcement, and extinction to treat food refusal. Journal of Applied Behavior Analysis. Win. 1998;31(4):691-694. X-3, X-10. [pmid: 9891407].
1081 Freeman NL, Perry A, Factor DC. Child behaviours as stressors: replicating and extending the use of the CARS as a measure of stress: a research note. J Child Psychol Psychiatry. 09. 1991;32(6):1025-30. X-1, X-3, X-4, X-10. [pmid: 1744190].
1082 Freitag CM, Luders E, Hulst HE, et al. Total brain volume and corpus callosum size in medication-naïve adolescents and young adults with autism spectrum disorder. Biological Psychiatry. 08. 2009;66(4):316-319. X-1, X-3, X-4. [pmid: 19409535].
1083 Friedman A, Luiselli JK. Excessive daytime sleep: Behavioral assessment and intervention in a child with autism. Behavior Modification. 07. 2008;32(4):548-555. X-1. [pmid: 18258994].
1084 Friis H, Bro F, Mabeck CE, et al. Use of antibiotics in general practice in Denmark in 1987. Scand J Infect Dis. 1989;21(5):551-6. X-1, X-3, X-4, X-10. [pmid: 2587956].
1085 Frimberger D, Schneede P, Hungerhuber E, et al. Autofluorescence and 5-aminolevulinic acid induced fluorescence diagnosis of penile carcinoma -- new techniques to monitor Nd:YAG laser therapy. Urol Res. 10. 2002;30(5):295-300. X-1, X-3, X-4. [pmid: 12389117].
1086 Fristoe M, Lloyd LL. Planning an initial expressive sign lexicon for persons with severe communication impairment. J Speech Hear Disord. 05. 1980;45(2):170-80. X-1, X-2, X-3, X-4, X-10. [pmid: 7442150].
1087 Frye CA, Bloom MS, Wersinger S. Androgens, autism and more. Physiol Behav. 2010. 01. 21. X-2, X-4.
1088 Fucilla R. Post-Crisis Intervention for Individuals with Autism Spectrum Disorder. Reclaiming Children and Youth: The Journal of Strength-based Interventions. Spr. 2005;14(1):44. X-1, X-2, X-3.
1089 Fudenberg HH. Dialysable lymphocyte extract (DLyE) in infantile onset autism: a pilot study. Biotherapy. 1996;9(1–3):143-7. X-10. [pmid: 8993773].
1090 Fuentes CT, Mostofsky SH, Bastian AJ. Children with autism show specific handwriting impairments. Neurology. 11. 10. 2009;73(19):1532-7. X-4. [pmid: 19901244].
1091 Fugain C, Meyer B, Chabolle F, et al. Clinical results of the French multichannel cochlear implant. Acta Otolaryngol Suppl. 1984;411:237-46. X-1, X-3, X-10. [pmid: 6596848].
1092 Fukuda H, Kawamoto M, Yuge O. Small dose of prostaglandin E(1) increases cardiac output without altering blood volume. J Clin Anesth. 08. 2001;13(5):330-4. X-1, X-3, X-4. [pmid: 11498312].
1093 Fukuta O, Braham RL, Yanase H, et al. The sedative effect of intranasal midazolam administration in the dental treatment of patients with mental disabilities. Part 1. The effect of a 0.2 mg/kg dose. J Clin Pediatr Dent. Summer. 1993;17(4):231-7. X-10. [pmid: 8217888].
1094 Funderburk SJ, Carter J, Tanguay P, et al. Parental reproductive problems and gestational hormonal exposure in autistic and schizophrenic children. J Autism Dev Disord. 09. 1983;13(3):325-32. X-4, X-10. [pmid: 6643376].
1095 Furneaux B. Keeping the balance right. Spec Educ Forward Trends. 06. 1984;11(2):15-6. X-10. [pmid: 6463757].
1096 Gabriels RL, Agnew JA, Miller LJ, et al. Is There a Relationship between Restricted, Repetitive, Stereotyped Behaviors and Interests and Abnormal Sensory Response in Children with Autism Spectrum Disorders?. Research in Autism Spectrum Disorders. 10. 2008;2(4):660-670. X-4.
1097 Gabriels RL, Cuccaro ML, Hill DE, et al. Repetitive behaviors in autism: relationships with associated clinical features. Res Dev Disabil. 03–04. 2005;26(2):169-81. X-4. [pmid: 15590247].
1098 Gadow KD, DeVincent CJ, Schneider J. Comparative Study of Children with ADHD Only, Autism Spectrum Disorder + ADHD, and Chronic Multiple Tic Disorder + ADHD. Journal of Attention Disorders. 2009;12(5):474-485. X-4. [pmid: 19218544].
1099 Gadow KD, Sprafkin J, Nolan EE. DSM-IVSymptoms in community and clinic preschool children. J Am Acad Child Adolesc Psychiatry. 12. 2001;40(12):1383-92. X-4. [pmid: 11765283].
1100 Gage NM, Siegel B, Callen M, et al. Cortical sound processing in children with autism disorder: an MEG investigation. Neuroreport. 11. 14. 2003;14(16):2047-51. X-3, X-4. [pmid: 14600495].
1101 Gage NM, Siegel B, Roberts TP. Cortical auditory system maturational abnormalities in children with autism disorder: an MEG investigation. Brain Res Dev Brain Res. 09. 10. 2003;144(2):201-9. X-4.
1102 Gagliano A, Germano E, Pustorino G, et al. Risperidone treatment of children with autistic disorder: effectiveness, tolerability, and pharmacokinetic implications. J Child Adolesc Psychopharmacol. Spring. 2004;14(1):39-47. X-3. [pmid: 15142390].
1103 Gaines R, Leaper C, Monahan C, et al. Language learning and retention in young language-disordered children. J Autism Dev Disord. 06. 1988;18(2):281-96. X-10. [pmid: 3410815].
1104 Galiatsatos GT, Graff RB. Combining descriptive and functional analyses to assess and treat screaming. Behavioral Interventions. 04. 2003;18(2):123-138. X-1, X-3.
1105 Gallagher A, Theriault M, Maclin E, et al. Near-infrared spectroscopy as an alternative to the Wada test for language mapping in children, adults and special populations. Epileptic Disord. 09. 2007;9(3):241-55. X-3, X-4. [pmid: 17884748].
1106 Gallagher TE. Augmentation of special-needs services and information to students and teachers “ASSIST”--a telehealth innovation providing school-based medical interventions. Hawaii Med J. 10. 2004;63(10):300-9. X-1, X-3, X-4. [pmid: 15570717].
1107 Gallate J, Chi R, Ellwood S, et al. Reducing false memories by magnetic pulse stimulation. Neurosci Lett. 01. 16. 2009;449(3):151-4. X-1, X-4. [pmid: 19022348].
1108 Gallese V, Eagle MN, Migone P. Intentional attunement: mirror neurons and the neural underpinnings of interpersonal relations. J Am Psychoanal Assoc. Winter. 2007;55(1):131-76. X-1, X-2, X-3, X-4. [pmid: 17432495].
1109 Galli Carminati G, Constantin N, Legay Y, et al. Evolution of 2 persons with severe disability over a period of 3 years: “Sonar Group” Underwater Music Therapy. European Journal of Psychiatry. 2004;18(Suppl):106-114. X-3.
1110 Galli-Carminati G, Deriaz N, Bertschy G. Melatonin in treatment of chronic sleep disorders in adults with autism: a retrospective study. Swiss Med Wkly. 05. 16. 2009;139(19–20):293-6. X-1, X-3. [pmid: 19452292].
1111 Gallo MT. The little alien: Links between mind and body in parentâ€”infant psychotherapy. Journal of Child Psychotherapy. 08. 1997;23(2):201-218. X-2, X-3, X-10.
1112 Gallucci G, Hackerman F, Schmidt CW. Gender Identity Disorder in an Adult Male with Asperger’s Syndrome. Sexuality and Disability. 03. 2005;23(1):35-40. X-1, X-3, X-4.
1113 Ganz JB. Using Visual Script Interventions to Address Communication Skills. TEACHING Exceptional Children. 11–12. 2007;40(2):54-58. X-1, X-2, X-3, X-4.
1114 Ganz JB. Self-Monitoring across Age and Ability Levels: Teaching Students to Implement Their Own Positive Behavioral Interventions. Preventing School Failure. Fall. 2008;53(1):39-48. X-1, X-2, X-3, X-4.
1115 Ganz JB, Bourgeois BC, Flores MM, et al. Implementing Visually Cued Imitation Training with Children with Autism Spectrum Disorders and Developmental Delays. Journal of Positive Behavior Interventions. 2008;10(1):56-66. X-3.
1116 Ganz JB, Flores MM. The Effectiveness of Direct Instruction for Teaching Language to Children with Autism Spectrum Disorders: Identifying Materials. Journal of Autism and Developmental Disorders. 01. 2009;39(1):75-83. X-3. [pmid: 18563547].
1117 Ganz JB, Kaylor M, Bourgeois B, et al. The Impact of Social Scripts and Visual Cues on Verbal Communication in Three Children with Autism Spectrum Disorders. Focus on Autism and Other Developmental Disabilities. 06. 2008;23(2):79-94. X-3.
1118 Ganz JB, Sigafoos J. Self-monitoring: Are Young Adults with MR and Autism able to Utilize Cognitive Strategies Independently?. Education and Training in Developmental Disabilities. 03. 2005;40(1):24-33. X-1, X-3.
1119 Ganz JB, Simpson RL. Effects on communicative requesting and speech development of the Picture Exchange Communication System in children with characteristics of autism. J Autism Dev Disord. 08. 2004;34(4):395-409. X-3. [pmid: 15449515].
1120 Ganz ML. The lifetime distribution of the incremental societal costs of autism. Arch Pediatr Adolesc Med. 04. 2007;161(4):343-9. X-1, X-3, X-4. [pmid: 17404130].
1121 Ganzer R, Blana A, Denzinger S, et al. Intraoperative photodynamic evaluation of surgical margins during endoscopic extraperitoneal radical prostatectomy with the use of 5-aminolevulinic acid. J Endourol. 09. 2009;23(9):1387-94. X-1, X-3, X-4. [pmid: 19673655].
1122 Garcaa-Villamisar D, Hughes C. Supported employment improves cognitive performance in adults with Autism. Journal of Intellectual Disability Research. 02. 2007;51(2):142-150. X-1, X-3. [pmid: 17217478].
1123 Garcaa-Villamisar D, Ross D, Wehman P. Clinical differential analysis of persons with autism in a work setting: A follow-up study. Journal of Vocational Rehabilitation. 2000;14(3):183-185. X-1, X-3, X-4.
1124 Garcaa-Villamisar D, Wehman P, Navarro MD. Changes in the quality of autistic people’s life that work in supported and sheltered employment. A 5-year follow-up study. Journal of Vocational Rehabilitation. 2002;17(4):309-312. X-1, X-3.
1125 Garcia-Perez RM, Hobson RP, Lee A. Narrative role-taking in autism. J Autism Dev Disord. 01. 2008;38(1):156-68. X-4. [pmid: 17447130].
1126 Garro A, Thurman SK, Kerwin ME, et al. Parent/caregiver stress during pediatric hospitalization for chronic feeding problems. J Pediatr Nurs. 08. 2005;20(4):268-75. X-1, X-4. [pmid: 16030506].
1127 Garstang J, Wallis M. Randomized controlled trial of melatonin for children with autistic spectrum disorders and sleep problems. Child Care Health Dev. 09. 2006;32(5):585-9. X-3. [pmid: 16919138].
1128 Gastaut H, Zifkin B, Rufo M. Compulsive respiratory stereotypies in children with autistic features: polygraphic recording and treatment with fenfluramine. J Autism Dev Disord. 09. 1987;17(3):391-406. X-3, X-10. [pmid: 3654490].
1129 Gaynor JW, Nord AS, Wernovsky G, et al. Apolipoprotein E genotype modifies the risk of behavior problems after infant cardiac surgery. Pediatrics. 07. 2009;124(1):241-50. X-1, X-4. [pmid: 19564306].
1130 Geier D, Geier MR. Neurodevelopmental disorders following thimerosal-containing childhood immunizations: a follow-up analysis. Int J Toxicol. 11–12. 2004;23(6):369-76. X-4. [pmid: 15764492].
1131 Geier DA, Geier MR. A comparative evaluation of the effects of MMR immunization and mercury doses from thimerosal-containing childhood vaccines on the population prevalence of autism. Med Sci Monit. 03. 2004;10(3):I33-9. X-4.
1132 Geier DA, Geier MR. An evaluation of serious neurological disorders following immunization: a comparison of whole-cell pertussis and acellular pertussis vaccines. Brain Dev. 08. 2004;26(5):296-300. X-4. [pmid: 15165669].
1133 Geier DA, Geier MR. A clinical trial of combined anti-androgen and anti-heavy metal therapy in autistic disorders. Neuro Endocrinol Lett. 12. 2006;27(6):833-8. X-3. [pmid: 17187010].
1134 Geier DA, Geier MR. A prospective assessment of androgen levels in patients with autistic spectrum disorders: biochemical underpinnings and suggested therapies. Neuro Endocrinol Lett. 10. 2007;28(5):565-73. X-4. [pmid: 17984958].
1135 Geier DA, Geier MR. A prospective study of mercury toxicity biomarkers in autistic spectrum disorders. J Toxicol Environ Health A. 10. 2007;70(20):1723-30. X-4. [pmid: 17885929].
1136 Geier DA, Kern JK, Garver CR, et al. Biomarkers of environmental toxicity and susceptibility in autism. Journal of the Neurological Sciences. 05. 2009;280(1–2):101-108. X-4. [pmid: 18817931].
1137 Geier MR, Geier DA. The potential importance of steroids in the treatment of autistic spectrum disorders and other disorders involving mercury toxicity. Med Hypotheses. 2005;64(5):946-54. X-2, X-3, X-4. [pmid: 15780490].
1138 Gena A. The effects of prompting and social reinforcement on establishing social interactions with peers during the inclusion of four children with autism in preschool. International Journal of Psychology. 12. 2006;41(6):541-554. X-3.
1139 Gena A, Couloura S, Kymissis E. Modifying the Affective Behavior of Preschoolers with Autism Using In-Vivo or Video Modeling and Reinforcement Contingencies. Journal of Autism and Developmental Disorders. 10. 2005;35(5):545-556. X-3. [pmid: 16163569].
1140 Gena A, Couloura S, Kymissis E. Modifying the affective behavior of preschoolers with autism using in-vivo or video modeling and reinforcement contingencies. J Autism Dev Disord. 10. 2005;35(5):545-56. X-3. [pmid: 16163569].
1141 Gena A, Krantz PJ, McClannahan LE, et al. Training and generalization of affective behavior displayed by youth with autism. J Appl Behav Anal. Fall. 1996;29(3):291-304. X-3, X-10. [pmid: 8926222].
1142 Gencer O, Emiroglu FN, Miral S, et al. Comparison of long-term efficacy and safety of risperidone and haloperidol in children and adolescents with autistic disorder. An open label maintenance study. Eur Child Adolesc Psychiatry. 06. 2008;17(4):217-25. X-1. [pmid: 18026891].
1143 Genuis SJ. Is autism reversible?. Acta Paediatr. 10. 2009;98(10):1575-8. X-1, X-2, X-3, X-4. [pmid: 19843021].
1144 Gerber S. A developmental perspective on language assessment and intervention for children on the autistic spectrum. Topics in Language Disorders. 04–06. 2003;23(2):74-94. X-3.
1145 Gerdtz J. Evaluating behavioral treatment of disruptive classroom behaviors of an adolescent with autism. Research on Social Work Practice. 01. 2000;10(1):98-110. X-1, X-3.
1146 Gergely Gr. The obscure object of desire: “Nearly, but clearly not, like me’: Contingency preference in normal children versus children with autism. Bulletin of the Menninger Clinic. Special Issue: Cognitive and interactional foundations of attachment. Sum. 2001;65(3):411-426. X-4.
1147 Gerig LH, Szanto J, Bichay T, et al. A translating-bed technique for total-body irradiation. Phys Med Biol. 01. 1994;39(1):19-35. X-1, X-2, X-3, X-4, X-10. [pmid: 7651996].
1148 Ghaziuddin M, Alessi N, Greden JF. Life events and depression in children with pervasive developmental disorders. J Autism Dev Disord. 10. 1995;25(5):495-502. X-4, X-10. [pmid: 8567595].
1149 Ghaziuddin M, Quinlan P, Ghaziuddin N. Catatonia in Autism: A Distinct Subtype?. Journal of Intellectual Disability Research. 01. 2005;49(1):102-105. X-2, X-3, X-4. [pmid: 15634317].
1150 Ghaziuddin M, Tsai L, Ghaziuddin N. Clonidine for autism. Journal of Child and Adolescent Psychopharmacology. Win. 1992;2(4):239-240. X-3, X-10. [pmid: 19630636].
1151 Ghaziuddin M, Tsai LY, Ghaziuddin N. Brief report: Haloperidol treatment of trichotillomania in a boy with autism and mental retardation. Journal of Autism and Developmental Disorders. 09. 1991;21(3):365-371. X-3, X-10. [pmid: 1938782].
1152 Ghezzi PM. Discrete Trials Teaching. Psychology in the Schools. 09. 2007;44(7):667-679. X-1, X-2, X-3, X-4.
1153 Ghika J. Paleoneurology: neurodegenerative diseases are age-related diseases of specific brain regions recently developed by Homo sapiens. Med Hypotheses. 11. 2008;71(5):788-801. X-1, X-2, X-3, X-4. [pmid: 18703290].
1154 Ghose K. Oxpentifylline in dementia: a controlled study. Arch Gerontol Geriatr. 04. 1987;6(1):19-26. X-1, X-2, X-3, X-4, X-10. [pmid: 3592847].
1155 Ghuman JK, Aman MG, Lecavalier L, et al. Randomized, placebo-controlled, crossover study of methylphenidate for attention-deficit/hyperactivity disorder symptoms in preschoolers with developmental disorders. J Child Adolesc Psychopharmacol. 08. 2009;19(4):329-39. X-3. [pmid: 19702485].
1156 Ghuman JK, Cataldo MD, Beck MH, et al. Behavioral training for pill-swallowing difficulties in young children with autistic disorder. J Child Adolesc Psychopharmacol. Winter. 2004;14(4):601-11. X-3. [pmid: 15662153].
1157 Ghuman JK, Ginsburg GS, Subramaniam G, et al. Psychostimulants in preschool children with attention-deficit/hyperactivity disorder: clinical evidence from a developmental disorders institution. J Am Acad Child Adolesc Psychiatry. 05. 2001;40(5):516-24. X-1, X-3, X-4. [pmid: 11349695].
1158 Giangreco MF, Broer SM. Questionable Utilization of Paraprofessionals in Inclusive Schools: Are We Addressing Symptoms or Causes?. Focus on Autism and Other Developmental Disabilities. 03. 2005;20(1):10-26. X-1, X-2, X-3, X-4.
1159 Giangreco MF, Broer SM. School-Based Screening to Determine Overreliance on Paraprofessionals. Focus on Autism and Other Developmental Disabilities. Fall. 2007;22(3):149-158. X-1, X-4.
1160 Giannotti F, Cortesi F, Cerquiglini A, et al. An open-label study of controlled-release melatonin in treatment of sleep disorders in children with autism. J Autism Dev Disord. 08. 2006;36(6):741-52. X-3. [pmid: 16897403].
1161 Giarelli E, Souders M, Pinto-Martin J, et al. Intervention pilot for parents of children with autistic spectrum disorder. Pediatr Nurs. 09–10. 2005;31(5):389-99. X-1, X-4. [pmid: 16295154].
1162 Gibbons MM, Goins S. Getting to Know the Child with Asperger Syndrome. Professional School Counseling. 06. 2008;11(5):347-352. X-1, X-2, X-3, X-4.
1163 Gibson JA, Grey IM, Hastings RP. Supervisor Support as a Predictor of Burnout and Therapeutic Self-Efficacy in Therapists Working in ABA Schools. Journal of Autism and Developmental Disorders. 07. 2009;39(7):1024-1030. X-1, X-4. [pmid: 19291383].
1164 Gidley Larson JC, Bastian AJ, Donchin O, et al. Acquisition of Internal Models of Motor Tasks in Children with Autism. Brain. 11. 2008;131(11):2894-2903. X-4. [pmid: 18819989].
1165 Gillberg C. The treatment of epilepsy in autism. J Autism Dev Disord. 03. 1991;21(1):61-77. X-1, X-2, X-3, X-4, X-10. [pmid: 2037550].
1166 Gillberg C. Endogenous opioids and opiate antagonists in autism: brief review of empirical findings and implications for clinicians. Dev Med Child Neurol. 03. 1995;37(3):239-45. X-1, X-2, X-3, X-4, X-10. [pmid: 7890130].
1167 Gillberg C, Johansson M, Steffenburg S, et al. Auditory integration training in children with autism. Autism. 07. 1997;1(1):97-100. X-3, X-10.
1168 Gillberg C, Wahlstrom J, Johansson R, et al. Folic acid as an adjunct in the treatment of children with the autism fragile-X syndrome (AFRAX). Dev Med Child Neurol. 10. 1986;28(5):624-7. X-3, X-10. [pmid: 3536640].
1169 Gillberg IC, Gillberg C, Rastam M, et al. The cognitive profile of anorexia nervosa: a comparative study including a community-based sample. Compr Psychiatry. 01–02. 1996;37(1):23-30. X-1, X-4, X-10. [pmid: 8770522].
1170 Gillberg IC, Rastam M, Gillberg C. Anorexia nervosa 6 years after onset: Part I. Personality disorders. Compr Psychiatry. 01–02. 1995;36(1):61-9. X-1, X-4, X-10. [pmid: 7705090].
1171 Gillett JN, LeBlanc LA. Parent-Implemented Natural Language Paradigm to Increase Language and Play in Children with Autism. Research in Autism Spectrum Disorders. 07–09. 2007;1(3):247-255. X-3.
1172 Gillis JM, Butler RC. Social Skills Interventions for Preschoolers with Autism Spectrum Disorder: A Description of Single-Subject Design Studies. Journal of Early and Intensive Behavior Intervention. 2007;4(3):532-547. X-1, X-2, X-3, X-4.
1173 Gillis JM, Natof TH, Lockshin SB, et al. Fear of routine physical exams in children with autism spectrum disorders: Prevalence and intervention effectiveness. Focus on Autism and Other Developmental Disabilities. 09. 2009;24(3):156-168. X-4.
1174 Girolametto L, Sussman F, Weitzman E. Using case study methods to investigate the effects of interactive intervention for children with autism spectrum disorders. J Commun Disord. 11–12. 2007;40(6):470-92. X-3. [pmid: 17169368].
1175 Glashan L, Mackay G, Grieve A. Teachers’ Experience of Support in the Mainstream Education of Pupils with Autism. Improving Schools. 2004;7(1):49-60. X-4.
1176 Glazebrook CM, Elliott D, Lyons J. Temporal judgements of internal and external events in persons with and without autism. Conscious Cogn. 03. 2008;17(1):203-9. X-4. [pmid: 17433718].
1177 Glogowska M, Roulstone S, Peters TJ, et al. Early speech- and language-impaired children: linguistic, literacy, and social outcomes. Dev Med Child Neurol. 06. 2006;48(6):489-94. X-1, X-2, X-3, X-4. [pmid: 16700942].
1178 Glover AC, Roane HS, Kadey HJ, et al. Preference for reinforcers under progressive- and fixed-ratio schedules: a comparison of single and concurrent arrangements. J Appl Behav Anal. Summer. 2008;41(2):163-76. X-1, X-3, X-4. [pmid: 18595281].
1179 Godby S, Gast DL, Wolery M. A comparison of time delay and system of least prompts in teaching object identification. Research in Developmental Disabilities. 1987;8(2):283-305. X-10. [pmid: 3671814].
1180 Goin-Kochel RP, Myers BJ, Mackintosh VH. Parental reports on the use of treatments and therapies for children with autism spectrum disorders. Research in Autism Spectrum Disorders. 07–09. 2007;1(3):195-209. X-4.
1181 Golan O, Baron-Cohen S. Systemizing empathy: teaching adults with Asperger syndrome or high-functioning autism to recognize complex emotions using interactive multimedia. Dev Psychopathol. Spring. 2006;18(2):591-617. X-1. [pmid: 16600069].
1182 Gold C, Wigram T, Elefant C. Music therapy for autistic spectrum disorder. Cochrane Database Syst Rev. 2006;(2):CD004381. X-2.
1183 Golden RR, Campbell M, Perry R. A taxometric method for diagnosis of tardive dyskinesia. J Psychiatr Res. 1987;21(3):233-41. X-1, X-2, X-3, X-4, X-10. [pmid: 2890764].
1184 Goldman S. Brief Report: Narratives of Personal Events in Children with Autism and Developmental Language Disorders--Unshared Memories. Journal of Autism and Developmental Disorders. 11. 2008;38(10):1982-1988. X-4. [pmid: 18512137].
1185 Goldsmith HH, Van Hulle CA, Arneson CL, et al. A population-based twin study of parentally reported tactile and auditory defensiveness in young children. J Abnorm Child Psychol. 06. 2006;34(3):393-407. X-1, X-4. [pmid: 16649001].
1186 Goldsmith TR, LeBlanc LA, Sautter RA. Teaching Intraverbal Behavior to Children with Autism. Research in Autism Spectrum Disorders. 01–03. 2007;1(1):1-13. X-3.
1187 Goldstein G, Minshew NJ, Siegel DJ. Age differences in academic achievement in high-functioning autistic individuals. J Clin Exp Neuropsychol. 10. 1994;16(5):671-80. X-4, X-10. [pmid: 7836490].
1188 Goldstein H, Cisar CL. Promoting interaction during sociodramatic play: teaching scripts to typical preschoolers and classmates with disabilities. J Appl Behav Anal. Summer. 1992;25(2):265-80. X-3, X-10. [pmid: 1386068].
1189 Goldstein H, Kaczmarek L, Pennington R, et al. Peer-mediated intervention: attending to, commenting on, and acknowledging the behavior of preschoolers with autism. J Appl Behav Anal. Summer. 1992;25(2):289-305. X-3, X-10. [pmid: 1634424].
1190 Goldstein H, Schneider N, Thiemann K. Peer-Mediated Social Communication Intervention: When Clinical Expertise Informs Treatment Development and Evaluation. Topics in Language Disorders. 04–06. 2007;27(2):182. X-1, X-2, X-3, X-4.
1191 Goldstein R, Joja O, Psatta DM, et al. Vasotocin improves intelligence and attention in mentally retarded children. Physiol Behav. 12. 1989;46(6):967-70. X-10. [pmid: 2634261].
1192 Golnik A, Ireland M, Borowsky IW. Medical homes for children with autism: a physician survey. Pediatrics. 03. 2009;123(3):966-71. X-1, X-2, X-3, X-4. [pmid: 19255027].
1193 Golnik AE, Ireland M. Complementary alternative medicine for children with autism: a physician survey. J Autism Dev Disord. 07. 2009;39(7):996-1005. X-1, X-3, X-4. [pmid: 19280328].
1194 Gombosi PG. Parents of autistic children. Some thoughts about trauma, dislocation, and tragedy. Psychoanal Study Child. 1998;53:254-75. X-1, X-4, X-10. [pmid: 9990834].
1195 Gomes E, Rotta NT, Pedroso FS, et al. Auditory hypersensitivity in children and teenagers with autistic spectrum disorder. Arq Neuropsiquiatr. 09. 2004;62(3B):797-801. X-4. [pmid: 15476072].
1196 Gomot M, Belmonte MK, Bullmore ET, et al. Brain hyper-reactivity to auditory novel targets in children with high-functioning autism. Brain. 09. 2008;131(Pt 9):2479-88. X-4. [pmid: 18669482].
1197 Gomot M, Bernard FA, Davis MH, et al. Change detection in children with autism: an auditory event-related fMRI study. Neuroimage. 01. 15. 2006;29(2):475-84. X-4. [pmid: 16115783].
1198 Gomot M, Giard MH, Adrien JL, et al. Hypersensitivity to acoustic change in children with autism: electrophysiological evidence of left frontal cortex dysfunctioning. Psychophysiology. 09. 2002;39(5):577-84. X-4. [pmid: 12236323].
1199 Gonzalez NM, Campbell M, Small AM, et al. Naltrexone plasma levels, clinical response and effect on weight in autistic children. Psychopharmacol Bull. 1994;30(2):203-8. X-10. [pmid: 7831456].
1200 Goodlin-Jones BL, Sitnick SL, Tang K, et al. The Children’s Sleep Habits Questionnaire in toddlers and preschool children. J Dev Behav Pediatr. 04. 2008;29(2):82-88. X-4. [pmid: 18478627].
1201 Goodman JF, Cecil HS, Barker WF. Early intervention with retarded children: some encouraging results. Dev Med Child Neurol. 02. 1984;26(1):47-55. X-1, X-10. [pmid: 6698326].
1202 Goodman JI, Brady MP, Duffy ML, et al. The Effects of “Bug-in-Ear” Supervision on Special Education Teachers’ Delivery of Learn Units. Focus on Autism and Other Developmental Disabilities. 2008;23(4):207-216. X-1, X-3, X-4.
1203 Goodman MJ, Nordin J. Vaccine adverse event reporting system reporting source: a possible source of bias in longitudinal studies. Pediatrics. 02. 2006;117(2):387-90. X-1, X-2, X-3, X-4. [pmid: 16452357].
1204 Goodwin MS. Enhancing and Accelerating the Pace of Autism Research and Treatment: The Promise of Developing Innovative Technology. Focus on Autism and Other Developmental Disabilities. 2008;23(2):125-128. X-1, X-2, X-3, X-4.
1205 Gordon B. Commentary: a neural systems perspective for improving behavioral treatments for autism. J Autism Dev Disord. 10. 2000;30(5):503-8. X-1, X-2, X-3, X-4. [pmid: 11098892].
1206 Gordon CT. Commentary: considerations on the pharmacological treatment of compulsions and stereotypies with serotonin reuptake inhibitors in pervasive developmental disorders. J Autism Dev Disord. 10. 2000;30(5):437-8. X-1, X-2, X-3, X-4. [pmid: 11098880].
1207 Gordon CT, Frazier JA, McKenna K, et al. Childhood-onset schizophrenia: an NIMH study in progress. Schizophr Bull. 1994;20(4):697-712. X-1, X-4, X-10. [pmid: 7701277].
1208 Gordon CT, Rapoport JL, Hamburger SD, et al. Differential response of seven subjects with autistic disorder to clomipramine and desipramine. Am J Psychiatry. 03. 1992;149(3):363-6. X-3, X-10. [pmid: 1536276].
1209 Gordon CT, State RC, Nelson JE, et al. A double-blind comparison of clomipramine, desipramine, and placebo in the treatment of autistic disorder. Arch Gen Psychiatry. 06. 1993;50(6):441-7. X-10. [pmid: 8498878].
1210 Gordon R, Handleman JS, Harris SL. The effects of contingent versus non-contingent running on the out-of-seat behavior of an autistic boy. Child & Family Behavior Therapy. Fal. 1986;8(3):37-44. X-3, X-10.
1211 Gorgels WJ, Oude Voshaar RC, Mol AJ, et al. Discontinuation of long-term benzodiazepine use by sending a letter to users in family practice: a prospective controlled intervention study. Drug Alcohol Depend. 04. 4. 2005;78(1):49-56. X-1, X-2, X-3, X-4. [pmid: 15769557].
1212 Gorham M, Barnes-Holmes Y, Barnes-Holmes D, et al. Derived Comparative and Transitive Relations in Young Children with and without Autism. Psychological Record. Spr. 2009;59(2):221-246. X-3.
1213 Gorman JM, Akande E, Xenitidis K, et al. Autism or schizophrenia: A diagnostic dilemma in adults with intellectual disabilities. Journal of Psychiatric Practice. 05. 2004;10(3):190-195. X-1, X-2, X-3, X-4. [pmid: 15330227].
1214 Gornick MC, Addington AM, Sporn A, et al. Dysbindin (DTNBP1, 6p22.3) is Associated with Childhood-Onset Psychosis and Endophenotypes Measured by the Premorbid Adjustment Scale (PAS). Journal of Autism and Developmental Disorders. 12. 2005;35(6):831-838. X-1, X-4. [pmid: 16283082].
1215 Gothelf D, Goraly O, Avni S, et al. Psychiatric morbidity with focus on obsessive-compulsive disorder in an Israeli cohort of adolescents with mild to moderate mental retardation. J Neural Transm. 06. 2008;115(6):929-36. X-1, X-4. [pmid: 18351287].
1216 Gottschalk JM, Libby ME, Graff RB. The effects of establishing operations on preference assessment outcomes. J Appl Behav Anal. Spring. 2000;33(1):85-8. X-3. [pmid: 10738955].
1217 Goulet M, Shiromani PJ, Ware CM, et al. A secretin i.v. infusion activates gene expression in the central amygdala of rats. Neuroscience. 2003;118(4):881-8. X-1, X-3, X-4. [pmid: 12732234].
1218 Graff RB, Gibson L. Using pictures to assess reinforcers in individuals with developmental disabilities. Behav Modif. 09. 2003;27(4):470-83. X-3, X-4. [pmid: 12971123].
1219 Graff RB, Green G. Two methods for teaching simple visual discriminations to learners with severe disabilities. Res Dev Disabil. 05–06. 2004;25(3):295-307. X-1, X-3. [pmid: 15134794].
1220 Graff RB, Green G, Libby ME. Effects of two levels of treatment intensity on a young child with severe disabilities. Behavioral Interventions. 02. 1998;13(1):21-41. X-3, X-10.
1221 Graff RB, Lineman GT, Libby ME, et al. Functional analysis and treatment of screaming in a young girl with severe disabilities. Behavioral Interventions. 10–12. 1999;14(4):233-239. X-3, X-10.
1222 Graham G. Music and Autism. Journal of Aesthetic Education. Sum. 2001;35(2):39-47. X-1, X-2, X-3, X-4.
1223 Gralton EJ, James DH, Lindsey MP. Antipsychotic medication, psychiatric diagnosis and children with intellectual disability: a 12-year follow-up study. J Intellect Disabil Res. 02. 1998;42(Pt 1):49-57. X-4, X-10. [pmid: 9534115].
1224 Grandin T. Brief report: response to National Institutes of Health report. J Autism Dev Disord. 04. 1996;26(2):185-7. X-1, X-2, X-3, X-4, X-10. [pmid: 8744482].
1225 Gray DE. Negotiating autism: relations between parents and treatment staff. Soc Sci Med. 04. 1993;36(8):1037-46. X-1, X-3, X-4, X-10. [pmid: 8475419].
1226 Gray DE, Holden WJ. Psycho-social well-being among the parents of children with autism. Australia & New Zealand Journal of Developmental Disabilities. 1992;18(2):83-93. X-1, X-3, X-4, X-10.
1227 Greaves N, Prince E, Evans DW, et al. Repetitive and Ritualistic Behaviour in Children with Prader-Willi Syndrome and Children with Autism. Journal of Intellectual Disability Research. 02. 2006;50(2):92-100. X-4. [pmid: 16403198].
1228 Green G, Brennan LC, Fein D. Intensive behavioral treatment for a toddler at high risk for autism. Behavior Modification. Special Issue: Autism, Part 2. 01. 2002;26(1):69-102. X-3.
1229 Green G, Striefel S. Response restriction and substitution with autistic children. J Exp Anal Behav. 07. 1988;50(1):21-32. X-3, X-4, X-10. [pmid: 3171473].
1230 Green VA. Parental experience with treatments for autism. Journal of Developmental and Physical Disabilities. 04. 2007;19(2):91-101. X-1, X-4.
1231 Green VA, Pituch KA, Itchon J, et al. Internet survey of treatments used by parents of children with autism. Res Dev Disabil. 01–02. 2006;27(1):70-84. X-1, X-4. [pmid: 15919178].
1232 Green VA, Sigafoos J, Pituch KA, et al. Assessing Behavioral Flexibility in Individuals with Developmental Disabilities. Focus on Autism and Other Developmental Disabilities. Win. 2006;21(4):230-236. X-1, X-4.
1233 Greenhill LL, Swanson JM, Vitiello B, et al. Impairment and deportment responses to different methylphenidate doses in children with ADHD: the MTA titration trial. J Am Acad Child Adolesc Psychiatry. 02. 2001;40(2):180-7. X-1, X-3, X-4. [pmid: 11211366].
1234 Greer RD, Yaun L, Gautreaux G. Novel dictation and intraverbal responses as a function of a multiple exemplar instructional history. Analysis of Verbal Behavior. 2005;21:99-116. X-1, X-3, X-4.
1235 Grela BG, McLaughlin KS. Focused stimulation for a child with autism spectrum disorder: a treatment study. J Autism Dev Disord. 08. 2006;36(6):753-6. X-3. [pmid: 16838131].
1236 Grieco A, Bloom R. Psychotherapy with hallucinogenic adjuncts from a learning perspective. Int J Addict. 07. 1981;16(5):801-27. X-1, X-2, X-3, X-4, X-10. [pmid: 7327766].
1237 Griffin HC, Griffin LW, Fitch CW, et al. Educational Interventions for Individuals with Asperger Syndrome. Intervention in School & Clinic. 01. 2006;41(3):150-155. X-1, X-2, X-3, X-4.
1238 Griffin JC, Ricketts RW, Williams DE, et al. A community survey of self-injurious behavior among developmentally disabled children and adolescents. Hosp Community Psychiatry. 09. 1987;38(9):959-63. X-4, X-10. [pmid: 3679101].
1239 Grimaldi BL. The central role of magnesium deficiency in Tourette’s syndrome: causal relationships between magnesium deficiency, altered biochemical pathways and symptoms relating to Tourette’s syndrome and several reported comorbid conditions. Med Hypotheses. 01. 2002;58(1):47-60. X-1, X-2, X-3. [pmid: 11863398].
1240 Grimbergen MC, van Swol CF, Jonges TG, et al. Reduced specificity of 5-ALA induced fluorescence in photodynamic diagnosis of transitional cell carcinoma after previous intravesical therapy. Eur Urol. 07. 2003;44(1):51-6. X-1, X-2, X-3, X-4. [pmid: 12814675].
1241 Grindle CF, Kovshoff H, Hastings RP, et al. Parents’ experiences of home-based applied behavior analysis programs for young children with autism. J Autism Dev Disord. 01. 2009;39(1):42-56. X-4. [pmid: 18535893].
1242 Grindle CF, Remington B. Discrete-trial training for autistic children when reward is delayed: A comparison of conditioned cue value and response marking. Journal of Applied Behavior Analysis. Sum. 2002;35(2):187-190. X-3. [pmid: 12102138].
1243 Grindle CF, Remington B. Teaching children with autism using conditioned cue-value and response-marking procedures: a socially valid procedure. Res Dev Disabil. 09–10. 2004;25(5):413-29. X-3. [pmid: 15217671].
1244 Grindle CF, Remington B. Teaching children with autism when reward is delayed. The effects of two kinds of marking stimuli. J Autism Dev Disord. 12. 2005;35(6):839-50. X-3. [pmid: 16283081].
1245 Gringras P, Santosh P, Baird G. Development of an Internet-based real-time system for monitoring pharmacological interventions in children with neurodevelopmental and neuropsychiatric disorders. Child Care Health Dev. 09. 2006;32(5):591-600. X-2, X-4. [pmid: 16919139].
1246 Grizenko N, Cvejic H, Vida S, et al. Behaviour problems of the mentally retarded. Can J Psychiatry. 12. 1991;36(10):712-7. X-4, X-10. [pmid: 1790515].
1247 Groden G, Groden J, Dondey M, et al. Effects of fenfluramine on the behavior of autistic individuals. Res Dev Disabil. 1987;8(2):203-11. X-3, X-10. [pmid: 3313552].
1248 Groden J, Cautela J. Procedures to increase social interaction among adolescents with autism: a multiple baseline analysis. J Behav Ther Exp Psychiatry. 06. 1988;19(2):87-93. X-1, X-3, X-10. [pmid: 3209701].
1249 Groen WB, van Orsouw L, Huurne N, et al. Intact spectral but abnormal temporal processing of auditory stimuli in autism. J Autism Dev Disord. 05. 2009;39(5):742-50. X-1, X-3, X-4. [pmid: 19148738].
1250 Groen WB, van Orsouw L, Zwiers M, et al. Gender in voice perception in autism. J Autism Dev Disord. 11. 2008;38(10):1819-26. X-4. [pmid: 18415010].
1251 Groen Y, Wijers AA, Mulder LJM, et al. Error and feedback processing in children with ADHD and children with autistic spectrum disorder: An EEG event-related potential study. Clinical Neurophysiology. 11. 2008;119(11):2476-2493. X-4. [pmid: 18824404].
1252 Groft-Jones M, Block ME. Strategies for Teaching Children with Autism in Physical Education. Teaching Elementary Physical Education. 11. 2006;17(6):25-28. X-1, X-2, X-3, X-4.
1253 Groskreutz MP, Graff RB. Evaluating Pictorial Preference Assessment: The Effect of Differential Outcomes on Preference Assessment Results. Research in Autism Spectrum Disorders. 01. 2009;3(1):113-128. X-3.
1254 Gross M. Pursuing the puzzle of autism. Curr Biol. 10. 15. 2002;12(20):R679. X-1, X-2, X-3, X-4. [pmid: 12401179].
1255 Grossman RB, Schneps MH, Tager-Flusberg H. Slipped lips: onset asynchrony detection of auditory-visual language in autism. J Child Psychol Psychiatry. 04. 2009;50(4):491-7. X-1, X-3, X-4. [pmid: 19207623].
1256 Grover S. Challenging Statutory Limitations on Children’s Education Rights: A Re-Examination of the Canadian Supreme Court Decision in “Auton”. Education and the Law. 03. 2005;17(1–2):43-52. X-1, X-2, X-3, X-4.
1257 Grow LL, Kelley ME, Roane HS, et al. Utility of extinction-induced response variability for the selection of mands. J Appl Behav Anal. Spring. 2008;41(1):15-24. X-3. [pmid: 18468276].
1258 Guardino CA. Identification and placement for deaf students with multiple disabilities: choosing the path less followed. Am Ann Deaf. Spring. 2008;153(1):55-64. X-1, X-2, X-4. [pmid: 18619069].
1259 Gudarzi SS, Yasamy M, Akhondzadeh S. Cyproheptadine in treatment of autism. European Psychiatry. 07. 2002;17(4):230-231. X-3. [pmid: 12231270].
1260 Guillem P, Cans C, Guinchat V, et al. Trends, perinatal characteristics, and medical conditions in pervasive developmental disorders. Dev Med Child Neurol. 11. 2006;48(11):896-900. X-4. [pmid: 17044957].
1261 Guilloteau D, Chalon S. PET and SPECT exploration of central monoaminergic transporters for the development of new drugs and treatments in brain disorders. Curr Pharm Des. 2005;11(25):3237-45. X-1, X-2, X-3, X-4. [pmid: 16250852].
1262 Guimaraes Filho PD. A hypothesis about the determining process of autistic states. Int J Psychoanal. 1990;71(Pt 3):393-402. X-1, X-2, X-4, X-10. [pmid: 2228439].
1263 Guldberg K, Pilkington R. Tutor Roles in Facilitating Reflection on Practice through Online Discussion. Educational Technology & Society. 2007;10(1):61-72. X-1, X-2, X-3, X-4.
1264 Gunter P, et al. The reduction of aberrant vocalizations with auditory feedback and resulting collateral behavior change of two autistic boys. Behavioral Disorders. 08. 1984;9(4):254-263. X-3, X-10.
1265 Gunter PL, Fox JJ, McEvoy MA, et al. A case study of the reduction of aberrant, repetitive responses of an adolescent with autism. Education & Treatment of Children. 05. 1993;16(2):187-197. X-1, X-3, X-10.
1266 Gupta S. Immunological treatments for autism. J Autism Dev Disord. 10. 2000;30(5):475-9. X-1, X-2, X-3, X-4. [pmid: 11098887].
1267 Gupta S, Aggarwal S, Heads C. Brief report: Dysregulated immune system in children with autism: Beneficial effects of intravenous immune globulin on autistic characteristics. Journal of Autism and Developmental Disorders. 08. 1996;26(4):439-452. X-10. [pmid: 8863094].
1268 Guptill JT, Booker AB, Gibbs TT, et al. [[superscript 3]H]-Flunitrazepam-Labeled Benzodiazepine Binding Sites in the Hippocampal Formation in Autism: A Multiple Concentration Autoradiographic Study. Journal of Autism and Developmental Disorders. 05. 2007;37(5):911-920. X-4. [pmid: 17019626].
1269 Gurney JG, Fritz MS, Ness KK, et al. Analysis of prevalence trends of autism spectrum disorder in Minnesota. Arch Pediatr Adolesc Med. 07. 2003;157(7):622-7. X-4. [pmid: 12860781].
1270 Gustafsson C, Ojehagen A, Hansson L, et al. Effects of Psychosocial Interventions for People with Intellectual Disabilities and Mental Health Problems: A Survey of Systematic Reviews. Research on Social Work Practice. 2009;19(3):281-290. X-1, X-2, X-3, X-4.
1271 Gutierrez A Jr, Hale MN, Gossens-Archuleta K, et al. Evaluating the Social Behavior of Preschool Children with Autism in an Inclusive Playground Setting. International Journal of Special Education. 2007;22(3):26-30. X-3.
1272 Gutierrez A Jr, Vollmer TR, Dozier CL, et al. Manipulating Establishing Operations to Verify and Establish Stimulus Control during Mand Training. Journal of Applied Behavior Analysis. Win. 2007;40(4):645-658. X-3. [pmid: 18189096].
1273 Guzzetta F, Battaglia D, Di Rocco C, et al. Symptomatic epilepsy in children with poroencephalic cysts secondary to perinatal middle cerebral artery occlusion. Childs Nerv Syst. 08. 2006;22(8):922-30. X-4. [pmid: 16816980].
1274 Haag G, Tordjman S, Duprat A, et al. Psychodynamic assessment of changes in children with autism under psychoanalytic treatment. Int J Psychoanal. 04. 2005;86(Pt 2):335-52. X-2. [pmid: 16089194].
1275 Hach I, Maywald U, Meusel D, et al. Continuity of long-term medication use after surgical hospital stay. Eur J Clin Pharmacol. 07. 2005;61(5–6):433-8. X-1, X-4. [pmid: 15947922].
1276 Hackett L, Shaikh S, Theodosiou L. Parental perceptions of the assessment of autistic spectrum disorders in a tier three service. Child and Adolescent Mental Health. 09. 2009;14(3):127-132. X-1, X-3, X-4.
1277 Hadwin J, Baron-Cohen S, Howlin P, et al. Can we teach children with autism to understand emotions, belief, or pretence?. Development and Psychopathology. Spr. 1996;8(2):345-365. X-10.
1278 Hadwin J, Baron-Cohen S, Howlin P, et al. Does teaching theory of mind have an effect on the ability to develop conversation in children with autism?. J Autism Dev Disord. 10. 1997;27(5):519-37. X-10. [pmid: 9403370].
1279 Hagerman RJ, Jackson C, Amiri K, et al. Girls with fragile X syndrome: physical and neurocognitive status and outcome. Pediatrics. 03. 1992;89(3):395-400. X-1, X-4, X-10. [pmid: 1741210].
1280 Hagermoser Sanetti LM, Luiselli JK, Handler MW. Effects of verbal and graphic performance feedback on behavior support plan implementation in a public elementary school. Behavior Modification. 07. 2007;31(4):454-465. X-1, X-4. [pmid: 17548540].
1281 Hagiwara T, Myles BS. A multimedia social story intervention: Teaching skills to children with autism. Focus on Autism and Other Developmental Disabilities. Sum. 1999;14(2):82-95. X-10.
1282 Hagner D, Cooney BF. “I Do That for Everybody”: Supervising Employees With Autism. Focus on Autism and Other Developmental Disabilities. Sum. 2005;20(2):91-97. X-1, X-4.
1283 Hagopian LP, Bruzek JL, Bowman LG, et al. Assessment and treatment of problem behavior occasioned by interruption of free-operant behavior. Journal of Applied Behavior Analysis. Spr. 2007;40(1):89-103. X-3. [pmid: 17471795].
1284 Hagopian LP, Crockett JL, van Stone M, et al. Effects of noncontingent reinforcement on problem behavior and stimulus engagement: The role of satiation, extinction, and alternative reinforcement. Journal of Applied Behavior Analysis. Special Issue: Establishing operations in applied behavior analysis. Win. 2000;33(4):433-449. X-3.
1285 Hagopian LP, Farrell DA, Amari A. Treating total liquid refusal with backward chaining and fading. Journal of Applied Behavior Analysis. Win. 1996;29(4):573-575. X-3, X-10. [pmid: 8995838].
1286 Hagopian LP, Fisher WW, Legacy SM. Schedule effects of noncontingent reinforcement on attention-maintained destructive behavior in identical quadruplets. Journal of Applied Behavior Analysis. Special Issue: Functional analysis approaches to behavioral assessment and treatment. Sum. 1994;27(2):317-325. X-10.
1287 Hagopian LP, Kuhn SA, Long ES, et al. Schedule thinning following communication training: using competing stimuli to enhance tolerance to decrements in reinforcer density. J Appl Behav Anal. Summer. 2005;38(2):177-93. X-3. [pmid: 16033165].
1288 Hagopian LP, Thompson RH. Reinforcement of compliance with respiratory treatment in a child with cystic fibrosis. Journal of Applied Behavior Analysis. Sum. 1999;32(2):233-236. X-3, X-10. [pmid: 10396778].
1289 Hagopian LP, Toole LM. Effects of response blocking and competing stimuli on stereotypic behavior. Behavioral Interventions. 04. 2009;24(2):117-125. X-3.
1290 Hagopian LP, Wilson DM, Wilder DA. Assessment and treatment of problem behavior maintained by escape from attention and access to tangible items. Journal of Applied Behavior Analysis. Sum. 2001;34(2):229-232. X-3. [pmid: 11421317].
1291 Hainsworth T. The prevalence and causes of autistic spectrum disorders. Nurs Times. 08. 1–7. 2006;102(31):23-4. X-1, X-2, X-3, X-4.
1292 Hairston MP. Analyses of responses of mentally retarded autistic and mentally retarded nonautistic children to art therapy and music therapy. Journal of Music Therapy. Fal. 1990;27(3):137-150. X-10.
1293 Halacheva K, Dimova S, Tolev T, et al. Elevated anticardiolipin antibodies in schizophrenic patients before and during neuroleptic medication. Psychiatry Res. 08. 30. 2009;169(1):51-5. X-1, X-4. [pmid: 19596154].
1294 Hall LJ. Effective behavioural strategies for the defining characteristics of autism. Behaviour Change. 1997;14(3):139-154. X-1, X-2, X-3, X-10.
1295 Halpin J, Nugent B. Health visitors’ perceptions of their role in autism spectrum disorder. Community Pract. 01. 2007;80(1):18-22. X-1.
1296 Hamdan-Allen G. Brief report: Trichotillomania in an autistic male. Journal of Autism and Developmental Disorders. 03. 1991;21(1):79-82. X-1, X-3, X-10. [pmid: 2037551].
1297 Hameury L, Roux S, Barthelemy C, et al. Quantified multidimensional assessment of autism and other pervasive developmental disorders. Application for bioclinical research. Eur Child Adolesc Psychiatry. 04. 1995;4(2):123-35. X-4, X-10. [pmid: 7796250].
1298 Hameury L, Roux S, Lenoir P, et al. Longitudinal study of autism and other pervasive developmental disorders: Review of 125 cases. Developmental Brain Dysfunction. 01–02. 1995;8(1):51-65. X-10 COMPREHENSIVE.
1299 Hamilton BL, Snell ME. Using the milieu approach to increase spontaneous communication book use across environments by an adolescent with autism. AAC: Augmentative and Alternative Communication. 12. 1993;9(4):259-272. X-10.
1300 Hamilton JD. The practical search. J Am Acad Child Adolesc Psychiatry. 03. 2007;46(3):418-22. X-1, X-2, X-3, X-4. [pmid: 17314728].
1301 Han I, Ling YH, al-Baker S, et al. Cellular pharmacology of liposomal cis-bis-neodecanoato-trans-R,R-1,2-diaminocyclohexaneplatinum(II) in A2780/S and A2780/PDD cells. Cancer Res. 10. 15. 1993;53(20):4913-9. X-1, X-3, X-4, X-10. [pmid: 8402681].
1302 Han I, Ling YH, Khokhar AR, et al. Cell death and DNA fragmentation induced by liposomal platinum(II) complex, L-NDDP in A2780 and A2780/PDD cells. Anticancer Res. 03–04. 1994;14(2A):421-6. X-1, X-3, X-4, X-10. [pmid: 8017841].
1303 Han I, Nguyen T, Yang LY, et al. Cellular accumulation and DNA damage induced by liposomal cis-bis-neodecanoato-trans-R,R-1,2-diaminocyclohexaneplatinum+ ++(II) in LoVo and LoVo/PDD cells. Anticancer Drugs. 02. 1994;5(1):64-8. X-1, X-4, X-10. [pmid: 8186432].
1304 Hancock TB, Kaiser AP. The effects of trainer-implemented Enhanced Milieu Teaching on the social communication of children with autism. Topics in Early Childhood Special Education. Spr. 2002;22(1):39-54. X-3.
1305 Handen BL, Apolito PM, Seltzer GB. Use of differential reinforcement of low rates of behavior to decrease repetitive speech in an autistic adolescent. Journal of Behavior Therapy and Experimental Psychiatry. 12. 1984;15(4):359-364. X-1, X-3, X-10. [pmid: 6526947].
1306 Handen BL, Hofkosh D. Secretin in Children with Autistic Disorder: A Double-Blind, Placebo-Controlled Trial. Journal of Developmental and Physical Disabilities. 06. 2005;17(2):95-106. X-3.
1307 Handen BL, Johnson CR, Lubetsky M. Efficacy of methylphenidate among children with autism and symptoms of attention-deficit hyperactivity disorder. J Autism Dev Disord. 06. 2000;30(3):245-55. X-3. [pmid: 11055460].
1308 Handen BL, Lubetsky M. Pharmacotherapy in Autism and Related Disorders. School Psychology Quarterly. Sum. 2005;20(2):155-171. X-1, X-2, X-3.
1309 Handen BL, Sahl R, Hardan AY. Guanfacine in children with autism and/or intellectual disabilities. J Dev Behav Pediatr. 08. 2008;29(4):303-8. X-3. [pmid: 18552703].
1310 Handleman JS, Powers MD, Harris SL. Teaching of labels: an analysis of concrete and pictorial representations. Am J Ment Defic. 05. 1984;88(6):625-9. X-3, X-10. [pmid: 6742000].
1311 Hanley GP, Piazza CC, Fisher WW, et al. On the Effectiveness of and Preference for Punishment and Extinction Components of Function-Based Interventions, Journal of Applied Behavior Analysis Journal Citation. Spr. 2005;38(1):51. Publisher: Department of Applied Behavioral Science. 1000 Sunnyside Ave., KU, Lawrence, KS 66045-2133. Web site: http://seab.envmed.rochester.edu. 2005 Pub Types: Journal Articles; Reports - Evaluative. X-3, X-4.
1312 Hanser GA, Erickson KA. Integrated Word Identification and Communication Instruction for Students with Complex Communication Needs: Preliminary Results. Focus on Autism and Other Developmental Disabilities. 2007;22(4):268-278. X-3.
1313 Hanson E, Kalish LA, Bunce E, et al. Use of complementary and alternative medicine among children diagnosed with autism spectrum disorder. J Autism Dev Disord. 04. 2007;37(4):628-36. X-1, X-4. [pmid: 16977497].
1314 Happe F. Theory of mind and the self. Ann N Y Acad Sci. 10. 2003;1001:134-44. X-1, X-2, X-4. [pmid: 14625359].
1315 Happe FG. An advanced test of theory of mind: understanding of story characters’ thoughts and feelings by able autistic, mentally handicapped, and normal children and adults. J Autism Dev Disord. 04. 1994;24(2):129-54. X-10. [pmid: 8040158].
1316 Harada Y, Tunoda M, Kanbayashi Y, et al. A case report of pervasive developmental disorder who fulfill the diagnostic criteria of attention-deficit/hyperactivity disorder. Journal of Mental Health No. 2002;48:67-70. X-3.
1317 Harbinson H, Alexander J. Asperger Syndrome and the English Curriculum: Addressing the Challenges. Support for Learning. 02. 2009;24(1):11-18. X-1, X-2, X-3, X-4.
1318 Harchik AE, Harchik AJ, Luce SC, et al. Teaching autistic and severely handicapped children to recruit praise: acquisition and generalization. Res Dev Disabil. 1990;11(1):77-95. X-10. [pmid: 2300688].
1319 Hardan AY, Handen BL. A retrospective open trial of adjunctive donepezil in children and adolescents with autistic disorder. J Child Adolesc Psychopharmacol. Fall. 2002;12(3):237-41. X-3. [pmid: 12427297].
1320 Hardan AY, Jou RJ, Handen BL. A retrospective assessment of topiramate in children and adolescents with pervasive developmental disorders. J Child Adolesc Psychopharmacol. Fall. 2004;14(3):426-32. X-1, X-3. [pmid: 15650499].
1321 Hardan AY, Jou RJ, Handen BL. Retrospective study of quetiapine in children and adolescents with pervasive developmental disorders. J Autism Dev Disord. 06. 2005;35(3):387-91. X-1, X-3, X-4. [pmid: 16119479].
1322 Harding JW, Wacker DP, Berg WK, et al. Assessment and treatment of severe behavior problems using choice-making procedures. Education & Treatment of Children. 02. 2002;25(1):26-46. X-3.
1323 Hare DJ. The use of cognitive-behavioral therapy with people with Asperger syndrome: A case study. Autism. 11. 1997;1(2):215-225. X-1, X-3, X-10.
1324 Hare DJ, Jones JPR, Paine C. Approaching reality: The use of personal construct assessment in working with people with Asperger syndrome. Autism. 06. 1999;3(2):165-176. X-1, X-3, X-10.
1325 Hare DJ, Pratt C, Burton M, et al. The health and social care needs of family carers supporting adults with autistic spectrum disorders. Autism. 12. 2004;8(4):425-44. X-1, X-4. [pmid: 15556960].
1326 Harel-Hochfeld M. Practicing choice theory and reality therapy in Israel: A case study. International Journal of Reality Therapy. Fal. 1999;19(1):32-34. X-3, X-10.
1327 Haring TG, Breen CG, Pitts-Conway V, et al. Use of differential reinforcement of other behavior during dyadic instruction to reduce stereotyped behavior of autistic students. American Journal of Mental Deficiency. 05. 1986;90(6):694-702. X-1, X-3, X-10. [pmid: 3717225].
1328 Haring TG, Kennedy CH. Contextual control of problem behavior in students with severe disabilities. J Appl Behav Anal. Summer. 1990;23(2):235-43. X-3, X-10. [pmid: 2142682].
1329 Haring TG, Kennedy CH, Adams MJ, et al. Teaching generalization of purchasing skills across community settings to autistic youth using videotape modeling. Journal of Applied Behavior Analysis. Spr. 1987;20(1):89-96. X-10. [pmid: 3583966].
1330 Harnryd C, Bjerkenstedt L, Bjork K, et al. Clinical evaluation of sulpiride in schizophrenic patients--a double-blind comparison with chlorpromazine. Acta Psychiatr Scand Suppl. 1984;311:7-30. X-1, X-4, X-10. [pmid: 6367364].
1331 Harpaz-Rotem I, Rosenheck RA. Changes in outpatient psychiatric diagnosis in privately insured children and adolescents from 1995 to 2000. Child Psychiatry Hum Dev. Summer. 2004;34(4):329-40. X-1, X-4. [pmid: 15039605].
1332 Harper CB, Symon JB, Frea WD. Recess is time-in: using peers to improve social skills of children with autism. J Autism Dev Disord. 05. 2008;38(5):815-26. X-3. [pmid: 17874290].
1333 Harrington JW, Patrick PA, Edwards KS, et al. Parental beliefs about autism: implications for the treating physician. Autism. 09. 2006;10(5):452-62. X-1, X-4. [pmid: 16940312].
1334 Harrington JW, Rosen L, Garnecho A, et al. Parental perceptions and use of complementary and alternative medicine practices for children with autistic spectrum disorders in private practice. J Dev Behav Pediatr. 04. 2006;27(2 Suppl):S156-61. X-1, X-4. [pmid: 16685182].
1335 Harris KM, Mahone EM, Singer HS. Nonautistic motor stereotypies: clinical features and longitudinal follow-up. Pediatr Neurol. 04. 2008;38(4):267-72. X-1, X-4. [pmid: 18358406].
1336 Harris SL. The family and the autistic child: A behavioral perspective. Family Relations. 01. 1984;33(1):127-134. X-1, X-2, X-3, X-4, X-10.
1337 Harris SL. The family of the autistic child: A behavioral-systems view. Clinical Psychology Review. 1984;4(3):227-239. X-1, X-2, X-4, X-10.
1338 Harris SL. Intervention planning for the family of the autistic child: A multilevel assessment of the family system. Journal of Marital & Family Therapy. 04. 1984;10(2):157-166. X-1, X-3, X-4, X-10.
1339 Harris SL. A 4- to 7-year questionnaire follow-up of participants in a training program for parents of autistic children. J Autism Dev Disord. 09. 1986;16(3):377-83. X-10. [pmid: 3558294].
1340 Harris SL. Brief report: A 4- to 7-year questionnaire follow-up of participants in a training program for parents of autistic children. Journal of Autism and Developmental Disorders. 09. 1986;16(3):377-383. X-10. [pmid: 3558294].
1341 Harris SL. Parents as teachers: A four to seven year follow up of parents of children with autism. Child & Family Behavior Therapy. Win. 1986;8(4):39-47. X-4, X-10.
1342 Harris SL. Adolescent with Autistic Spectrum Disorder and some Obsessive-Compulsive Disorder behavior. J Autism Dev Disord. 12. 2003;33(6):709. X-1, X-2, X-3, X-4. [pmid: 14714938].
1343 Harris SL. My 19-year-old son has autism and moderate mental retardation. What can I do to make him less passive?. J Autism Dev Disord. 02. 2005;35(1):137. X-1, X-3. [pmid: 15796130].
1344 Harris SL. Setting up a home-based program for our 3-year-old son who has autism. J Autism Dev Disord. 02. 2006;36(2):293. X-1, X-2, X-3, X-4. [pmid: 16763777].
1345 Harris SL, Handleman JS, Alessandri M. Teaching youths with autism to offer assistance. J Appl Behav Anal. Fall. 1990;23(3):297-305. X-3, X-10. [pmid: 2249966].
1346 Harris SL, Handleman JS, Fong PL. Imitation of self-stimulation: Impact on the autistic child’s behavior and affect. Child & Family Behavior Therapy. Spr-Sum. 1987;9(1–2):1-21. X-3, X-10.
1347 Harris SL, Handleman JS, Gill MJ, et al. Does punishment hurt? The impact of aversives on the clinician. Res Dev Disabil. 1991;12(1):17-24. X-1, X-4, X-10. [pmid: 2017584].
1348 Harris SL, Handleman JS, Gordon R, et al. Changes in cognitive and language functioning of preschool children with autism. J Autism Dev Disord. 09. 1991;21(3):281-90. X-10. [pmid: 1938774].
1349 Harris SL, Handleman JS, Kristoff B, et al. Changes in language development among autistic and peer children in segregated and integrated preschool settings. J Autism Dev Disord. 03. 1990;20(1):23-31. X-10. [pmid: 2324053].
1350 Harris SL, Wolchik SA, Milch RE. Changing the speech of autistic children and their parents. Child & Family Behavior Therapy. Sum-Fal. 1982;4(2–3):151-173. X-3, X-10.
1351 Harris SL, Wolchik SA, Weitz S. The acquisition of language skills by autistic children: can parents do the job?. J Autism Dev Disord. 12. 1981;11(4):373-84. X-10. [pmid: 7052814].
1352 Harris TA, Peterson SL, Filliben TL, et al. Evaluating a more cost-efficient alternative to providing in-home feedback to parents: the use of spousal feedback. J Appl Behav Anal. Spring. 1998;31(1):131-4. X-1, X-3, X-4, X-10. [pmid: 9532757].
1353 Harrison Elder J, Shankar M, Shuster J, et al. The Gluten-Free, Casein-Free Diet In Autism: Results of A Preliminary Double Blind Clinical Trial. Journal of Autism and Developmental Disorders. 04. 2006;36(3):413-420. X-3. [pmid: 16555138].
1354 Harrison JR, Barabasz AF. Effects of restricted environmental stimulation therapy on the behavior of children with autism. Child Study Journal. 1991;21(3):153-166. X-10.
1355 Harrison RM. Low energy X-ray depth dose data for use in radiotherapy--comments on the review of BJR Supplement 17. Br J Radiol. 09. 1997;70(837):946-9. X-1, X-4, X-10. [pmid: 9498916].
1356 Harrison S, Berry L. Valuing people: health visiting and people with learning disabilities. Community Pract. 02. 2006;79(2):56-9. X-2, X-4. [pmid: 16493981].
1357 Harte HA. What Teachers Can Learn from Mothers of Children with Autism. TEACHING Exceptional Children. 09–10. 2009;42(1):24-30. X-1, X-3, X-4.
1358 Hartley SL, Sikora DM, McCoy R. Prevalence and Risk Factors of Maladaptive Behaviour in Young Children with Autistic Disorder. Journal of Intellectual Disability Research. 10. 2008;52(10):819-829. X-4. [pmid: 18444989].
1359 Hartman BA, Miller BK, Nelson DL. The effects of hands-on occupation versus demonstration on children’s recall memory. Am J Occup Ther. 09–10. 2000;54(5):477-83. X-1, X-4. [pmid: 11006807].
1360 Hartshorne TS, Herr MD. An Adlerian approach to autism. Individual Psychology: Journal of Adlerian Theory, Research & Practice. 12. 1983;39(4):394-401. X-3, X-10.
1361 Hartz I, Sakshaug S, Furu K, et al. Aspects of statin prescribing in Norwegian counties with high, average and low statin consumption - an individual-level prescription database study. BMC Clin Pharmacol. 2007;7:14. X-1, X-4. [pmid: 18053228].
1362 Harvey RJ, Cooray SE. The effective treatment of severe repetitive behaviour with fluvoxamine in a 20 year old autistic female. International Clinical Psychopharmacology. 09. 1995;10(3):201-203. X-1, X-3, X-10. [pmid: 8675975].
1363 Hassert DL, Kelly AN, Pritchard JK, et al. The Licensing of Behavior Analysts: Protecting the Profession and the Public. Journal of Early and Intensive Behavior Intervention. 2008;5(2):8-19. X-1, X-2, X-4.
1364 Hastings RP. Behavioral adjustment of siblings of children with autism engaged in applied behavior analysis early intervention programs: the moderating role of social support. J Autism Dev Disord. 04. 2003;33(2):141-50. X-1, X-4. [pmid: 12757353].
1365 Hastings RP, Beck A, Daley D, et al. Symptoms of ADHD and Their Correlates in Children with Intellectual Disabilities. Research in Developmental Disabilities: A Multidisciplinary Journal. 09–10. 2005;26(5):456-468. X-4.
1366 Hastings RP, Johnson E. Stress in UK families conducting intensive home-based behavioral intervention for their young child with autism. J Autism Dev Disord. 06. 2001;31(3):327-36. X-1, X-4. [pmid: 11518485].
1367 Hastings RP, Symes MD. Early intensive behavioral intervention for children with autism: parental therapeutic self-efficacy. Res Dev Disabil. 09–10. 2002;23(5):332-41. X-4. [pmid: 12401484].
1368 Hatton C, Emerson E, Robertson J, et al. The Resident Choice Scale: a measure to assess opportunities for self-determination in residential settings. J Intellect Disabil Res. 02. 2004;48(Pt 2):103-13. X-1, X-4. [pmid: 14723653].
1369 Hatton DD, Wheeler AC, Skinner ML, et al. Adaptive behavior in children with fragile X syndrome. Am J Ment Retard. 11. 2003;108(6):373-90. X-4. [pmid: 14561110].
1370 Haugaard JJ. Recognizing and treating rare behavioral and emotional disorders in children and adolescents who have been severely maltreated: schizophrenia. Child Maltreat. 05. 2004;9(2):161-8. X-1, X-2, X-4. [pmid: 15104885].
1371 Hausman N, Kahng S, Farrell E, et al. Idiosyncratic functions: Severe problem behavior maintained by access to ritualistic behaviors. Education and Treatment of Children. 02. 2009;32(1):77-87. X-3.
1372 Hawkins AH. Influencing leisure choices of autisticlike children. J Autism Dev Disord. 12. 1982;12(4):359-66. X-3, X-10. [pmid: 7161237].
1373 Hayashi E. Effect of melatonin on sleep-wake rhythm: The sleep diary of an autistic male. Psychiatry and Clinical Neurosciences. 06. 2000;54(3):383. X-1, X-3. [pmid: 11186124].
1374 Hazell P. Drug therapy for attention-deficit/hyperactivity disorder-like symptoms in autistic disorder. J Paediatr Child Health. 01–02. 2007;43(1–2):19-24. X-1, X-2, X-3. [pmid: 17207050].
1375 Hazell PL, Tarren-Sweeney M, Vimpani GV, et al. Children with disruptive behaviours I: service utilization. J Paediatr Child Health. 02. 2002;38(1):27-31. X-1, X-4. [pmid: 11869397].
1376 Hazell PL, Tarren-Sweeney M, Vimpani GV, et al. Children with disruptive behaviours II: clinical and community service needs. J Paediatr Child Health. 02. 2002;38(1):32-40. X-1, X-4. [pmid: 11869398].
1377 Healey JJ, Ahearn WH, Graff RB, et al. Extended analysis and treatment of self-injurious behavior. Behavioral Interventions. 07–09. 2001;16(3):181-195. X-1, X-3.
1378 Healy O, O’Connor J, Leader G, et al. Three Years of Intensive Applied Behavior Analysis: A Case Study. Journal of Early and Intensive Behavior Intervention. 2008;5(1):4-22. X-3.
1379 Heckaman KA, Alber S, Hooper S, et al. A comparison of least-to-most prompts and progressive time delay on the disruptive behavior of students with autism. Journal of Behavioral Education. 06. 1998;8(2):171-201. X-10.
1380 Hedbring C, Newsom C. Visual overselectivity: a comparison of two instructional remediation procedures with autistic children. J Autism Dev Disord. 03. 1985;15(1):9-22. X-10. [pmid: 3980432].
1381 Hedenbro M, Tjus T. A Case Study of Parent-Child Interactions of a Child with Autistic Spectrum Disorder (3–48 Months) and Comparison with Typically-Developing Peers. Child Language Teaching and Therapy. 2007;23(2):201-222. X-3, X-4.
1382 Hediger ML, England LJ, Molloy CA, et al. Reduced bone cortical thickness in boys with autism or autism spectrum disorder. Journal of Autism and Developmental Disorders. 05. 2008;38(5):848-856. X-4. [pmid: 17879151].
1383 Hedley D, Young R. Social Comparison Processes and Depressive Symptoms in Children and Adolescents with Asperger Syndrome. Autism: The International Journal of Research & Practice. 2006;10(2):139-153. X-4. [pmid: 16613864].
1384 Heering PW, Wilder DA, Ladd C. Liquid rescheduling for the treatment of rumination. Behavioral Interventions. 07. 2003;18(3):199-207. X-1, X-3.
1385 Heidgerken AD, Geffken G, Modi A, et al. A Survey of Autism Knowledge in a Health Care Setting. Journal of Autism and Developmental Disorders. 06. 2005;35(3):323-330. X-1, X-4. [pmid: 16119473].
1386 Heilbrun AB Jr, Blum N, Goldreyer N. Defensive projection. An investigation of its role in paranoid conditions. J Nerv Ment Dis. 01. 1985;173(1):17-25. X-4, X-10. [pmid: 3965607].
1387 Heiman T, Berger O. Parents of Children with Asperger Syndrome or with Learning Disabilities: Family Environment and Social Support. Research in Developmental Disabilities: A Multidisciplinary Journal. 07–08. 2008;29(4):289-300. X-1, X-4.
1388 Heimann M, Nelson KE, Tjus T, et al. Increasing reading and communication skills in children with autism through an interactive multimedia computer program. J Autism Dev Disord. 10. 1995;25(5):459-80. X-10. [pmid: 8567593].
1389 Heinrich H, Gevensleben H, Strehl U. Annotation: neurofeedback - train your brain to train behaviour. J Child Psychol Psychiatry. 01. 2007;48(1):3-16. X-1, X-4. [pmid: 17244266].
1390 Hellemans H, Colson K, Verbraeken C, et al. Sexual behavior in high-functioning male adolescents and young adults with autism spectrum disorder. J Autism Dev Disord. 02. 2007;37(2):260-9. X-4. [pmid: 16868848].
1391 Hellings JA, Kelley LA, Gabrielli WF, et al. Sertraline response in adults with mental retardation and autistic disorder. J Clin Psychiatry. 08. 1996;57(8):333-6. X-1, X-3, X-10. [pmid: 8778118].
1392 Hellings JA, Nickel EJ, Weckbaugh M, et al. The overt aggression scale for rating aggression in outpatient youth with autistic disorder: preliminary findings. J Neuropsychiatry Clin Neurosci. Winter. 2005;17(1):29-35. X-4. [pmid: 15746480].
1393 Hellings JA, Weckbaugh M, Nickel EJ, et al. A double-blind, placebo-controlled study of valproate for aggression in youth with pervasive developmental disorders. J Child Adolesc Psychopharmacol. 08. 2005;15(4):682-92. X-1, X-4. [pmid: 16190799].
1394 Hellings JA, Zarcone JR, Crandall K, et al. Weight gain in a controlled study of risperidone in children, adolescents and adults with mental retardation and autism. J Child Adolesc Psychopharmacol. Fall. 2001;11(3):229-38. X-1, X-3. [pmid: 11642473].
1395 Hellings JA, Zarcone JR, Reese RM, et al. A crossover study of risperidone in children, adolescents and adults with mental retardation. J Autism Dev Disord. 04. 2006;36(3):401-11. X-1, X-3. [pmid: 16596465].
1396 Hellings JA, Zarcone JR, Valdovinos MG, et al. Risperidone-induced prolactin elevation in a prospective study of children, adolescents, and adults with mental retardation and pervasive developmental disorders. J Child Adolesc Psychopharmacol. 12. 2005;15(6):885-92. X-1, X-3. [pmid: 16379508].
1397 Henderson LM. Asperger’s Syndrome in Gifted Individuals. Gifted Child Today. Sum. 2001;24(3):28-35. X-1, X-2, X-4.
1398 Hendren RL, Hodde-Vargas JE, Vargas LA, et al. Magnetic resonance imaging of severely disturbed children--a preliminary study. J Am Acad Child Adolesc Psychiatry. 05. 1991;30(3):466-70. X-4, X-10. [pmid: 2055885].
1399 Henley D. Emotional handicaps in low-functioning children: Art educational/art therapeutic interventions. The Arts in Psychotherapy. Spr. 1986;13(1):35-44. X-1, X-3, X-10.
1400 Henley D. Naming the Enemy: An Art Therapy Intervention for Children with Bipolar and Comorbid Disorders. Art Therapy: Journal of the American Art Therapy Association. 2007;24(3):104-110. X-1, X-4.
1401 Hennessy MJ, Haas RH. The orthopedic management of Rett syndrome. J Child Neurol. 1988;3(Suppl):S43-7. X-1, X-4, X-10. [pmid: 3198902].
1402 Henry CA, Shervin D, Neumeyer A, et al. Retrial of selective serotonin reuptake inhibitors in children with pervasive developmental disorders: a retrospective chart review. J Child Adolesc Psychopharmacol. 04. 2009;19(2):111-7. X-3. [pmid: 19364289].
1403 Herbert M. Martha Herbert, MD: transcending the gaps in autism research. Interview by Frank Lampe and Suzanne Snyder. Altern Ther Health Med. 11–12. 2007;13(6):62-73. X-1, X-2, X-3.
1404 Herbrecht E, Poustka F, Birnkammer S, et al. Pilot evaluation of the Frankfurt Social Skills Training for children and adolescents with autism spectrum disorder. Eur Child Adolesc Psychiatry. 06. 2009;18(6):327-35. X-1, X-3. [pmid: 19165532].
1405 Herman BH, Asleson GS, Powell A, et al. Cardiovascular and other physical effects of acute administration of naltrexone in autistic children. Journal of Child and Adolescent Psychopharmacology. Fal. 1993;3(3):157-168. X-10. [pmid: 19630675].
1406 Herman BH, Hammock MK, Arthur-Smith A, et al. Effects of acute administration of naltrexone on cardiovascular function, body temperature, body weight and serum concentrations of liver enzymes in autistic children. Dev Pharmacol Ther. 1989;12(3):118-27. X-3, X-10. [pmid: 2721334].
1407 Hernandez-Reif M, Martinez A, Field T, et al. Premenstrual symptoms are relieved by massage therapy. J Psychosom Obstet Gynaecol. 03. 2000;21(1):9-15. X-1, X-4. [pmid: 10907210].
1408 Herndon AC, DiGuiseppi C, Johnson SL, et al. Does nutritional intake differ between children with autism spectrum disorders and children with typical development?. Journal of Autism and Developmental Disorders. 2009;39(2):462593. X-4.
1409 Herrera G, Alcantud F, Jordan R, et al. Development of Symbolic Play through the Use of Virtual Reality Tools in Children with Autistic Spectrum Disorders: Two Case Studies. Autism: The International Journal of Research and Practice. 2008;12(2):143-157. X-3. [pmid: 18308764].
1410 Herring S, Gray K, Taffe J, et al. Behaviour and Emotional Problems in Toddlers with Pervasive Developmental Disorders and Developmental Delay: Associations with Parental Mental Health and Family Functioning. Journal of Intellectual Disability Research. 12. 2006;50(12):874-882. X-4. [pmid: 17100948].
1411 Hertzman M. Galantamine in the treatment of adult autism: A report of three clinical cases. International Journal of Psychiatry in Medicine. 2003;33(4):395-398. X-1, X-3, X-4. [pmid: 15152789].
1412 Hess KL, Morrier MJ, Heflin LJ, et al. Autism treatment survey: services received by children with autism spectrum disorders in public school classrooms. J Autism Dev Disord. 05. 2008;38(5):961-71. X-1, X-4. [pmid: 17929155].
1413 Hess L. I Would Like to Play but I Don’t Know How: A Case Study of Pretend Play in Autism. Child Language Teaching and Therapy. 2006;22(1):97-116. X-3.
1414 Hetzroni OE, Shalem U. From Logos to Orthographic Symbols: A Multilevel Fading Computer Program for Teaching Nonverbal Children with Autism. Focus on Autism and Other Developmental Disabilities. Win. 2005;20(4):201-212. X-3.
1415 Hetzroni OE, Tannous J. Effects of a computer-based intervention program on the communicative functions of children with autism. J Autism Dev Disord. 04. 2004;34(2):95-113. X-3. [pmid: 15162930].
1416 Hewitt LE. A social interactionist view of autism and its clinical management. J Commun Disord. 03–04. 1998;31(2):87-92. X-10. [pmid: 9549668].
1417 Hickling EJ, Blanchard EB, Kuhn E. Brief, Early Treatment for ASD/PTSD Following Motor Vehicle Accidents. Cognitive and Behavioral Practice. Aut. 2005;12(4):461-467. X-1, X-3, X-4.
1418 Higbee TS, Carr JE, Patel MR. The effects of interpolated reinforcement on resistance to extinction in children diagnosed with autism: a preliminary investigation. Res Dev Disabil. 01–02. 2002;23(1):61-78. X-3. [pmid: 12071396].
1419 Higgins DJ, Bailey SR, Pearce JC. Factors associated with functioning style and coping strategies of families with a child with an autism spectrum disorder. Autism. 05. 2005;9(2):125-37. X-1, X-4. [pmid: 15857858].
1420 Higgins KK, Koch LC, Boughfman EM, et al. School-to-work transition and Asperger Syndrome. Work. 2008;31(3):291-8. X-1, X-2, X-3, X-4. [pmid: 19029670].
1421 Hill BK, Balow EA, Bruininks RH. A national study of prescribed drugs in institutions and community residential facilities for mentally retarded people. Psychopharmacol Bull. 1985;21(2):279-84. X-10. [pmid: 4001292].
1422 Hillier A, Campbell H, Keillor J, et al. Decreased false memory for visually presented shapes and symbols among adults on the autism spectrum. J Clin Exp Neuropsychol. 08. 2007;29(6):610-6. X-1. [pmid: 17691033].
1423 Hillier A, Campbell H, Mastriani K, et al. Two-year evaluation of a vocational support program for adults on the autism spectrum. Career Development for Exceptional Individuals. Spr. 2007;30(1):35-47. X-1, X-3, X-4.
1424 Hilton JC, Seal BC. Brief report: comparative ABA and DIR trials in twin brothers with autism. J Autism Dev Disord. 07. 2007;37(6):1197-201. X-3. [pmid: 17072747].
1425 Hilton S, Hunt K, Langan M, et al. Reporting of MMR evidence in professional publications: 1988–2007. Arch Dis Child. 11. 2009;94(11):831-3. X-1, X-2, X-3, X-4. [pmid: 19414434].
1426 Hilton S, Hunt K, Petticrew M. MMR: marginalised, misrepresented and rejected? Autism: a focus group study. Arch Dis Child. 04. 2007;92(4):322-7. X-1, X-3, X-4. [pmid: 17376937].
1427 Hine JF, Wolery M. Using Point-of-View Video Modeling to Teach Play to Preschoolers with Autism. Topics in Early Childhood Special Education. Sum. 2006;26(2):83-93. X-3.
1428 Hinerman PS, Jenson WR, Walker GR, et al. Positive practice overcorrection combined with additional procedures to teach signed words to an autistic child. Journal of Autism and Developmental Disorders. 09. 1982;12(3):253-263. X-10. [pmid: 7153200].
1429 Hirose M, Kijima R, Shirakawa K, et al. Development of a virtual sand box: an application of virtual environment for psychological treatment. Stud Health Technol Inform. 1997;44:113-20. X-2, X-4, X-10. [pmid: 10184810].
1430 Hirsch N, Myles BS. The use of a pica box in reducing pica behavior in a student with autism. Focus on Autism and Other Developmental Disabilities. Win. 1996;11(4):222-225. 234. X-3, X-10.
1431 Hittner JB. Case study: The combined use of imipramine and behavior modification to reduce aggression in an adult male diagnosed as having autistic disorder. Behavioral Interventions. 04. 1994;9(2):123-139. X-1, X-3, X-10.
1432 Ho HH, Lockitch G, Eaves L, et al. Blood serotonin concentrations and fenfluramine therapy in autistic children. J Pediatr. 03. 1986;108(3):465-9. X-10. [pmid: 2936877].
1433 Ho HH, Miller A, Armstrong RW. Parent-professional agreement on diagnosis and recommendations for children with developmental disorders. Child Health Care. Spring. 1994;23(2):137-48. X-4, X-10. [pmid: 10146014].
1434 Hoch H, McComas JJ, Johnson L, et al. The effects of magnitude and quality of reinforcement on choice responding during play activities. Journal of Applied Behavior Analysis. Sum. 2002;35(2):171-181. X-3. [pmid: 12102136].
1435 Hoch H, McComas JJ, Thompson AL, et al. Concurrent reinforcement schedules: Behavior change and maintenance without extinction. Journal of Applied Behavior Analysis. Sum. 2002;35(2):155-169. X-3. [pmid: 12102135].
1436 Hoda MR, Popken G. Surgical outcomes of fluorescence-guided laparoscopic partial nephrectomy using 5-aminolevulinic acid-induced protoporphyrin IX. J Surg Res. 06. 15. 2009;154(2):220-5. X-1, X-3, X-4. [pmid: 19375717].
1437 Hoevenaars-van den Boom MAA, Antonissen ACFM, Knoors H, et al. Differentiating Characteristics of Deafblindness and Autism in People with Congenital Deafblindness and Profound Intellectual Disability. Journal of Intellectual Disability Research. 06. 2009;53(6):548-558. X-4. [pmid: 19457155].
1438 Hoff RG, van Dijk GW, Algra A, et al. Fluid balance and blood volume measurement after aneurysmal subarachnoid hemorrhage. Neurocrit Care. 2008;8(3):391-7. X-1, X-4. [pmid: 18172784].
1439 Hoffman CD, Sweeney DP, Gilliam JE, et al. Sleep Problems and Symptomology in Children With Autism. Focus on Autism and Other Developmental Disabilities. Win. 2005;20(4):194-200. X-4.
1440 Hoffman CD, Sweeney DP, Hodge D, et al. Parenting Stress and Closeness: Mothers of Typically Developing Children and Mothers of Children with Autism. Focus on Autism and Other Developmental Disabilities. 2009;24(3):178-187. X-1, X-3, X-4.
1441 Hofvander B, Delorme R, Chaste P, et al. Psychiatric and psychosocial problems in adults with normal-intelligence autism spectrum disorders. BMC Psychiatry. 2009;9:35. X-1, X-4. [pmid: 19515234].
1442 Hoksbergen R, ter Laak J, Rijk K, et al. Post-Institutional Autistic Syndrome in Romanian adoptees. J Autism Dev Disord. 10. 2005;35(5):615-23. X-4. [pmid: 16167089].
1443 Holburn CS. Counter the mistreatments for autism with professional integrity. Intellect Dev Disabil. 04. 2007;45(2):136-7. X-1, X-2, X-3, X-4. [pmid: 17428138].
1444 Holck U. Interaction Themes in Music Therapy: Definition and Delimitation. Nordic Journal of Music Therapy. 2004;13(1):3-19. X-1, X-2, X-4.
1445 Holcomb MJ, Pufpaff LA, McIntosh DE. Obesity Rates in Special Populations of Children and Potential Interventions. Psychology in the Schools. 09. 2009;46(8):797-804. X-1, X-2, X-3, X-4.
1446 Holden B, Gitlesen JP. A Total Population Study of Challenging Behaviour in the County of Hedmark, Norway: Prevalence, and Risk Markers. Research in Developmental Disabilities: A Multidisciplinary Journal. 07–08. 2006;27(4):456-465. X-4.
1447 Hollander A, Hebborn-Brass U. Termination of long term treatment in a residential home: quotas, conditions and additional comments. Acta Paedopsychiatr. 1989;52(4):243-53. X-4, X-10. [pmid: 2518648].
1448 Hollander E, Bartz J, Chaplin W, et al. Oxytocin increases retention of social cognition in autism. Biol Psychiatry. 02. 15. 2007;61(4):498-503. X-1. [pmid: 16904652].
1449 Hollander E, Chaplin W, Soorya L, et al. Divalproex Sodium vs Placebo for the Treatment of Irritability in Children and Adolescents with Autism Spectrum Disorders. Neuropsychopharmacology. 03. 2010;35(4):990-8. X-3. [pmid: 20010551].
1450 Hollander E, Dolgoff-Kaspar R, Cartwright C, et al. An open trial of divalproex sodium in autism spectrum disorders. J Clin Psychiatry. 07. 2001;62(7):530-4. X-1, X-3. [pmid: 11488363].
1451 Hollander E, Kaplan A, Cartwright C, et al. Venlafaxine in children, adolescents, and young adults with autism spectrum disorders: an open retrospective clinical report. J Child Neurol. 02. 2000;15(2):132-5. X-1, X-3. [pmid: 10695900].
1452 Hollander E, Novotny S, Allen A, et al. The relationship between repetitive behaviors and growth hormone response to sumatriptan challenge in adult autistic disorder. Neuropsychopharmacology. 02. 2000;22(2):163-167. X-1. [pmid: 10649829].
1453 Hollander E, Novotny S, Hanratty M, et al. Oxytocin infusion reduces repetitive behaviors in adults with autistic and Asperger’s disorders. Neuropsychopharmacology. 01. 2003;28(1):193-8. X-1. [pmid: 12496956].
1454 Hollander E, Phillips AT, Yeh CC. Targeted treatments for symptom domains in child and adolescent autism. Lancet. 08. 30. 2003;362(9385):732-4. X-1, X-2, X-3, X-4. [pmid: 12957098].
1455 Hollander E, Soorya L, Wasserman S, et al. Divalproex sodium vs. placebo in the treatment of repetitive behaviours in autism spectrum disorder. Int J Neuropsychopharmacol. 04. 2006;9(2):209-13. X-1, X-3. [pmid: 16316486].
1456 Hollander E, Wasserman S, Swanson EN, et al. A double-blind placebo-controlled pilot study of olanzapine in childhood/adolescent pervasive developmental disorder. J Child Adolesc Psychopharmacol. 10. 2006;16(5):541-8. X-3. [pmid: 17069543].
1457 Holmes DL. Community-based services for children and adults with autism: the Eden Family of Programs. J Autism Dev Disord. 09. 1990;20(3):339-51. X-1, X-2, X-3, X-4, X-10. [pmid: 2228916].
1458 Holmes N, Carr J. The pattern of care in families of adults with a mental handicap: a comparison between families of autistic adults and Down syndrome adults. J Autism Dev Disord. 06. 1991;21(2):159-76. X-4, X-10. [pmid: 1830876].
1459 Holmes N, Hemsley R, Rickett J, et al. Parents as cotherapists: their perceptions of a home-based behavioral treatment for autistic children. J Autism Dev Disord. 12. 1982;12(4):331-42. X-1, X-4, X-10. [pmid: 7161235].
1460 Holmstrom C. Autism. Can J Psychiatr Nurs. 07–09. 1989;30(3):6-8. X-10.
1461 Holttum JR, Lubetsky MJ, Eastman LE. Comprehensive management of trichotillomania in a young autistic girl. Journal of the American Academy of Child & Adolescent Psychiatry. 05. 1994;33(4):577-581. X-3, X-10. [pmid: 8005911].
1462 Holzer L, Mihailescu R, Rodrigues-Degaeff C, et al. Community introduction of practice parameters for autistic spectrum disorders: Advancing early recognition. J Autism Dev Disord. 02. 2006;36(2):249-62. X-1, X-4. [pmid: 16447011].
1463 Honda H, Shimizu Y. Early intervention system for preschool children with autism in the community: the DISCOVERY approach in Yokohama, Japan. Autism. 09. 2002;6(3):239-57. X-1, X-2, X-4. [pmid: 12212916].
1464 Honda H, Shimizu Y, Imai M, et al. Cumulative incidence of childhood autism: a total population study of better accuracy and precision. Dev Med Child Neurol. 01. 2005;47(1):10-8. X-4. [pmid: 15686284].
1465 Honda H, Shimizu Y, Nitto Y, et al. Extraction and Refinement Strategy for detection of autism in 18-month-olds: a guarantee of higher sensitivity and specificity in the process of mass screening. J Child Psychol Psychiatry. 08. 2009;50(8):972-81. X-4. [pmid: 19298465].
1466 Honda H, Shimizu Y, Rutter M. No effect of MMR withdrawal on the incidence of autism: a total population study. J Child Psychol Psychiatry. 06. 2005;46(6):572-9. X-1, X-4. [pmid: 15877763].
1467 Honey E, McConachie H, Randle V, et al. One-year change in repetitive behaviours in young children with communication disorders including autism. J Autism Dev Disord. 09. 2008;38(8):1439-50. X-4. [pmid: 16900401].
1468 Honeycutt N, Belcher JR. Schizophrenia and social skills: an ‘identify and train’ approach. Community Ment Health J. 02. 1991;27(1):57-68. X-1, X-2, X-4, X-10. [pmid: 2019099].
1469 Honomichl RD, Goodlin-Jones BL, Burnham MM, et al. Secretin and sleep in children with autism. Child Psychiatry Hum Dev. Winter. 2002;33(2):107-23. X-3. [pmid: 12462350].
1470 Hori T, Yagi S, Iida T, et al. Stability of cirrhotic systemic hemodynamics ensures sufficient splanchnic blood flow after living-donor liver transplantation in adult recipients with liver cirrhosis. World J Gastroenterol. 11. 28. 2007;13(44):5918-25. X-1, X-4. [pmid: 17990357].
1471 Hori T, Yamamoto C, Yagi S, et al. Assessment of cardiac output in liver transplantation recipients. Hepatobiliary Pancreat Dis Int. 08. 2008;7(4):362-6. X-1, X-4. [pmid: 18693170].
1472 Horner RH, Budd CM. Acquisition of manual sign use: Collateral reduction of maladaptive behavior, and factors limiting generalization. Education & Training of the Mentally Retarded. 03. 1985;20(1):39-47. X-3, X-10.
1473 Horner RH, Carr EG, Strain PS, et al. Problem behavior interventions for young children with autism: a research synthesis. J Autism Dev Disord. 10. 2002;32(5):423-46. X-1, X-2, X-3, X-4. [pmid: 12463518].
1474 Horowitz LT. Early intervention in autism (0–3)/South Carolina services and how to access them. J S C Med Assoc. 10. 2006;102(8):282-4. X-2. [pmid: 17319245].
1475 Horrigan JP, Barnhill LJ. More on melatonin. Journal of the American Academy of Child & Adolescent Psychiatry. 08. 1997;36(8):1014. X-1, X-3, X-10.
1476 Horrigan JP, Barnhill LJ. Risperidone and explosive aggressive autism. J Autism Dev Disord. 06. 1997;27(3):313-23. X-10. [pmid: 9229261].
1477 Horrocks JL, White G, Roberts L. Principals’ attitudes regarding inclusion of children with autism in Pennsylvania public schools. J Autism Dev Disord. 09. 2008;38(8):1462-73. X-1, X-4. [pmid: 18256916].
1478 Hoshino Y, Kaneko M, Yashima Y, et al. Self-mutilative behavior and its treatment in autistic children. Fukushima J Med Sci. 07. 1983;29(3–4):133-40. X-10. [pmid: 6678779].
1479 Hoshino Y, Kumashiro H, Yashima Y, et al. Early symptoms of autistic children and its diagnostic significance. Folia Psychiatr Neurol Jpn. 1982;36(4):367-74. X-1, X-4, X-10. [pmid: 7169196].
1480 Hoshino Y, Murata S, Endo M, et al. A consideration of the effectiveness of a training camp for autistic children--by means of the new check-list method. Fukushima J Med Sci. 07. 1983;29(3–4):125-32. X-10. [pmid: 6678778].
1481 Hoshino Y, Watanabe H, Yashima Y, et al. An investigation on sleep disturbance of autistic children. Folia Psychiatr Neurol Jpn. 1984;38(1):45-51. X-4, X-10. [pmid: 6537391].
1482 Houlihan D, Jacobson L, Brandon PK. Replication of a high-probability request sequence with varied interprompt times in a preschool setting. Journal of Applied Behavior Analysis. Special Issue: Integrating basic and applied research. Win. 1994;27(4):737-738. X-3, X-10.
1483 Hourcade J, Pilotte TE, West E, et al. A History of Augmentative and Alternative Communication for Individuals with Severe and Profound Disabilities. Focus on Autism and Other Developmental Disabilities. Win. 2004;19(4):235-244. X-1, X-2, X-4.
1484 Hourigan R, Hourigan A. Teaching Music to Children with Autism: Understandings and Perspectives. Music Educators Journal. 2009;96(1):40-45. X-1, X-2, X-3, X-4.
1485 Houzel D. Precipitation anxiety and the dawn of aesthetic feelings. Journal of Child Psychotherapy. 1989;15(2):103-114. X-3, X-10.
1486 Howlin P. The results of a home-based language training programme with autistic children. Br J Disord Commun. 09. 1981;16(2):73-88. X-10. [pmid: 7326212].
1487 Howlin P. A brief report on the elimination of long term sleeping problems in a 6-yr-old autistic boy. Behavioural Psychotherapy. 07. 1984;12(3):257-260. X-3, X-10.
1488 Howlin P. Can early interventions alter the course of autism?. Novartis Found Symp. 2003;251:250-9. discussion 260–5, 281–97. X-1, X-2, X-3, X-4. [pmid: 14521197].
1489 Howlin P. The effectiveness of interventions for children with autism. J Neural Transm Suppl. 2005;(69):101-19. X-1, X-2, X-3, X-4.
1490 Howlin P, Alcock J, Burkin C. An 8 year follow-up of a specialist supported employment service for high-ability adults with autism or Asperger syndrome. Autism. 12. 2005;9(5):533-549. X-1, X-4. [pmid: 16287704].
1491 Howlin P, Clements J. Is it possible to assess the impact of abuse on children with pervasive developmental disorders?. J Autism Dev Disord. 08. 1995;25(4):337-54. X-4, X-10. [pmid: 7592248].
1492 Howlin P, Goode S, Hutton J, et al. Adult outcome for children with autism. J Child Psychol Psychiatry. 02. 2004;45(2):212-29. X-1, X-4. [pmid: 14982237].
1493 Howlin P, Magiati I, Charman T. Systematic Review of Early Intensive Behavioral Interventions for Children with Autism. American Journal on Intellectual and Developmental Disabilities. 01. 2009;114(1):23-41. X-1, X-3, X-4. [pmid: 19143460].
1494 Howlin P, Mawhood L, Rutter M. Autism and developmental receptive language disorder--a follow-up comparison in early adult life. II: Social, behavioural, and psychiatric outcomes. J Child Psychol Psychiatry. 07. 2000;41(5):561-78. X-1, X-4. [pmid: 10946749].
1495 Howlin P, Rutter M. Mothers’ speech to autistic children: a preliminary causal analysis. J Child Psychol Psychiatry. 11. 1989;30(6):819-43. X-10. [pmid: 2592467].
1496 Howlin P, Wing L, Gould J. The recognition of autism in children with Down syndrome: Implications for intervention and some speculations about pathology. Developmental Medicine & Child Neurology. 05. 1995;37(5):406-413. X-3, X-4, X-10. [pmid: 7768340].
1497 Howlin P, Yates P. The potential effectiveness of social skills groups for adults with autism. Autism. 09. 1999;3(3):299-307. X-1, X-4, X-10.
1498 Howlin PA. The effectiveness of operant language training with autistic children. J Autism Dev Disord. 03. 1981;11(1):89-105. X-1, X-2, X-3, X-4, X-10. [pmid: 6927701].
1499 Hoy JA, Hatton C, Hare D. Weak central coherence: a cross-domain phenomenon specific to autism?. Autism. 09. 2004;8(3):267-81. X-4. [pmid: 15358870].
1500 Hsieh LP, Huang CY. Antiepileptic drug utilization in Taiwan: analysis of prescription using National Health Insurance database. Epilepsy Res. 03. 2009;84(1):21-7. X-1, X-2, X-4. [pmid: 19135869].
1501 Huang AX, Wheeler JJ. Promoting the Development of Educational Programs for Children with Autism in Southeast Asian Countries. International Journal of Special Education. 2007;22(3):78-88. X-1, X-2, X-3, X-4.
1502 Hubel M, Hagell P, Sivberg B. Brief Report: development and initial testing of a questionnaire version of the Environmental Rating Scale (ERS) for assessment of residential programs for individuals with autism. J Autism Dev Disord. 07. 2008;38(6):1178-83. X-1, X-4. [pmid: 17987373].
1503 Hudry K, Leadbitter K, Temple K, et al. Preschoolers with autism show greater impairment in receptive compared with expressive language abilities. Int J Lang Commun Disord. 2010. 01. 26. X-4.
1504 Hughes C, Soares-Boucaud I, Hochmann J, et al. Social behaviour in pervasive developmental disorders: effects of informant, group and “theory-of-mind”. Eur Child Adolesc Psychiatry. 12. 1997;6(4):191-8. X-4, X-10. [pmid: 9442997].
1505 Hughes DM, Cunningham MM, Libretto SE. Risperidone in children and adolescents with autistic disorder and aggressive behaviour. British Journal of Developmental Disabilities. 07. 2002;48(95,Pt2):113-122. X-1, X-3.
1506 Hughes JR. A review of recent reports on autism: 1000 studies published in 2007. Epilepsy Behav. 10. 2008;13(3):425-37. X-2. [pmid: 18627794].
1507 Hughes JR. Update on autism: a review of 1300 reports published in 2008. Epilepsy Behav. 12. 2009;16(4):569-89. X-2, X-3. [pmid: 19896907].
1508 Hughes JR, Melyn M. EEG and seizures in autistic children and adolescents: further findings with therapeutic implications. Clin EEG Neurosci. 01. 2005;36(1):15-20. X-4. [pmid: 15683193].
1509 Hughes V, Wolery MR, Neel RS. Teacher verbalizations and task performance with autistic children. J Autism Dev Disord. 09. 1983;13(3):305-16. X-3, X-10. [pmid: 6643375].
1510 Humble M, Bejerot S, Bergqvist PB, et al. Reactivity of serotonin in whole blood: relationship with drug response in obsessive-compulsive disorder. Biol Psychiatry. 02. 15. 2001;49(4):360-8. X-1, X-4. [pmid: 11239907].
1511 Hume K, Bellini S, Pratt C. The usage and perceived outcomes of early intervention and early childhood programs for young children with autism spectrum disorder. Topics in Early Childhood Special Education. Win. 2005;25(4):195-207. X-1, X-3, X-4.
1512 Hume K, Loftin R, Lantz J. Increasing Independence in Autism Spectrum Disorders: A Review of Three Focused Interventions. Journal of Autism and Developmental Disorders. 09. 2009;39(9):1329-1338. X-1, X-2, X-3, X-4. [pmid: 19430897].
1513 Hume K, Odom S. Effects of an individual work system on the independent functioning of students with autism. J Autism Dev Disord. 07. 2007;37(6):1166-80. X-3. [pmid: 17072746].
1514 Humphrey N, Lewis S. ‘Make me normal’: the views and experiences of pupils on the autistic spectrum in mainstream secondary schools. Autism. 01. 2008;12(1):23-46. X-4. [pmid: 18178595].
1515 Humphries T. Effectiveness of pivotal response training as a behavioral intervention for young children with autism spectrum disorders. Bridges. 2003;2:1-10. UNABLE TO LOCATE DOCUMENT.
1516 Hung DW. Training and generalization of yes and no as mands in two autistic children. J Autism Dev Disord. 06. 1980;10(2):139-52. X-3, X-10. [pmid: 6927683].
1517 Hung DW, Rotman Z, Cosentino A, et al. Cost and effectiveness of an educational program for autistic children using a systems approach. Education and Treatment of Children. Win. 1983;6(1):47-68. X-10.
1518 Hungerhuber E, Stepp H, Kriegmair M, et al. Seven years’ experience with 5-aminolevulinic acid in detection of transitional cell carcinoma of the bladder. Urology. 02. 2007;69(2):260-4. X-1, X-4. [pmid: 17320660].
1519 Hunt A. A comparison of the abilities, health and behaviour of 23 people with tuberous sclerosis at Age 5 and as adults. Journal of Applied Research in Intellectual Disabilities. 1998;11(3):227-238. X-1, X-4, X-10.
1520 Hunt P, Goetz L. Teaching spontaneous communication in natural settings through interrupted behavior chains. Topics in Language Disorders. 12. 1988;9(1):58-71. X-1, X-2, X-3, X-4, X-10.
1521 Hupp SDA, Reitman D. Parent-assisted modification of pivotal social skills for a child diagnosed with PDD: A clinical replication. Journal of Positive Behavior Interventions. Sum. 2000;2(3):183-187. X-3.
1522 Hurley AD, Folstein M, Lam N. Patients with and without intellectual disability seeking outpatient psychiatric services: diagnoses and prescribing pattern. J Intellect Disabil Res. 01. 2003;47(Pt 1):39-50. X-1, X-4. [pmid: 12558694].
1523 Hutchins TL, Prelock PA. Using social stories and comic strip conversations to promote socially valid outcomes for children with autism. Seminars in Speech & Language. 02. 2005;27(1):47-59. X-3.
1524 Hutton AM, Caron SL. Experiences of Families with Children with Autism in Rural New England. Focus on Autism and Other Developmental Disabilities. Fall. 2005;20(3):180-189. X-1, X-4.
1525 Huynen KB, Lutzker JR, Bigelow KM, et al. Planned Activities Training for mothers of children with developmental disabilities. Community generalization and follow-up. Behav Modif. 10. 1996;20(4):406-27. X-1, X-3, X-10. [pmid: 8875813].
1526 Hwang B, Hughes C. The effects of social interactive training on early social communicative skills of children with autism. J Autism Dev Disord. 08. 2000;30(4):331-43. X-1, X-2, X-3, X-4. [pmid: 11039859].
1527 Hwang SS, Chang JS, Lee KY, et al. Causal model of insight and psychopathology based on the PANSS factors: 1-year cross-sectional and longitudinal revalidation. Int Clin Psychopharmacol. 07. 2009;24(4):189-98. X-1, X-3, X-4. [pmid: 19521247].
1528 Hyman M. Standing at Sinai with Autism: A Young Man’s Bar Mitzvah Journey. Journal of Positive Behavior Interventions. 2009;11(3):186-192. X-1, X-2, X-3, X-4.
1529 Hyman MH. The impact of mercury on human health and the environment. Altern Ther Health Med. 11–12. 2004;10(6):70-5. X-1, X-2, X-3, X-4.
1530 Hyman SL, Levy SE. Introduction: novel therapies in developmental disabilities--hope, reason, and evidence. Ment Retard Dev Disabil Res Rev. 2005;11(2):107-9. X-1, X-2, X-3, X-4. [pmid: 15977317].
1531 Iancu I, Strous R, Poreh A, et al. Psychiatric inpatients’ reactions to the SARS epidemic: an Israeli survey. Isr J Psychiatry Relat Sci. 2005;42(4):258-62. X-1, X-4. [pmid: 16618059].
1532 Ihrig K, Wolchik SA. Peer versus adult models and autistic children’s learning: acquisition, generalization, and maintenance. J Autism Dev Disord. 03. 1988;18(1):67-79. X-3, X-10. [pmid: 3372460].
1533 Ijichi S, Ijichi N. Beyond negative data in autism randomized trials. Autism. 03. 2004;8(1):111-2. X-1, X-2, X-3, X-4. [pmid: 15070551].
1534 Ijichi S, Ijichi N. Computerized lifelong mentoring support using robot for autistic individuals. Med Hypotheses. 2007;68(3):493-8. X-1, X-2, X-3, X-4. [pmid: 17023117].
1535 Inadomi C, Terao Y, Yamashita K, et al. Comparison of oxygen consumption calculated by Fick’s principle (using a central venous catheter) and measured by indirect calorimetry. J Anesth. 2008;22(2):163-6. X-1, X-3, X-4. [pmid: 18500614].
1536 Infantino J, Hempenstall K. Effects of a Decoding Program on a Child with Autism Spectrum Disorder. Australasian Journal of Special Education. 2006;30(2):126-144. X-3.
1537 Ingenmey R, Van Houten R. Using time delay to promote spontaneous speech in an autistic child. Journal of Applied Behavior Analysis. Fal. 1991;24(3):591-596. X-10. [pmid: 1752846].
1538 Ingersoll B, Dvortcsak A. Including Parent Training in the Early Childhood Special Education Curriculum for Children with Autism Spectrum Disorders. Topics in Early Childhood Special Education. Fall. 2006;26(3):179-187. X-3.
1539 Ingersoll B, Dvortcsak A, Whalen C, et al. The Effects of a Developmental, Social-Pragmatic Language Intervention on Rate of Expressive Language Production in Young Children With Autistic Spectrum Disorders. Focus on Autism and Other Developmental Disabilities. Win. 2005;20(4):213-222. X-3.
1540 Ingersoll B, Gergans S. The effect of a parent-implemented imitation intervention on spontaneous imitation skills in young children with autism. Res Dev Disabil. 03–04. 2007;28(2):163-75. X-3. [pmid: 16603337].
1541 Ingersoll B, Lewis E, Kroman E. Teaching the imitation and spontaneous use of descriptive gestures in young children with autism using a naturalistic behavioral intervention. J Autism Dev Disord. 09. 2007;37(8):1446-56. X-3. [pmid: 17033930].
1542 Ingersoll B, Schreibman L. Teaching reciprocal imitation skills to young children with autism using a naturalistic behavioral approach: effects on language, pretend play, and joint attention. J Autism Dev Disord. 05. 2006;36(4):487-505. X-3. [pmid: 16568355].
1543 Ingersoll B, Schreibman L, Stahmer A. Brief report: Differential treatment outcomes for children with autistic spectrum disorder based on level of peer social avoidance. J Autism Dev Disord. 06. 2001;31(3):343-9. X-3. [pmid: 11518487].
1544 Ingvarsson ET, Kahng S, Hausman NL. Some Effects of Noncontingent Positive Reinforcement on Multiply Controlled Problem Behavior and Compliance in a Demand Context. Journal of Applied Behavior Analysis. Fall. 2008;41(3):435-440. X-3. [pmid: 18816983].
1545 Insel TR. Mouse models for autism: report from a meeting. Mamm Genome. 10. 2001;12(10):755-7. X-1, X-2, X-4. [pmid: 11678137].
1546 Irvin DS. Using analog assessment procedures for determining the effects of a gluten-free and casein-free diet on rate of problem behaviors for an adolescent with autism. Behavioral Interventions. 11. 2006;21(4):281-286. X-1, X-3.
1547 Israel ML, Connolly DA, von Heyn RE, et al. Teaching severely self-abusive and aggressive autistic residents to exit to fire alarms. J Behav Ther Exp Psychiatry. 12. 1993;24(4):343-55. X-10. [pmid: 8077453].
1548 Ivancic Jokic N, Majstorovic M, Bakarcic D, et al. Dental caries in disabled children. Coll Antropol. 03. 2007;31(1):321-4. X-4. [pmid: 17598418].
1549 Ivanov I, Klein M, Green WH, et al. The Challenges of Psychopharmacological Management of Children with Severe Developmental Disabilities. Journal of Child and Adolescent Psychopharmacology. 12. 2006;16(6):793-799. X-3. [pmid: 17201623].
1550 Ivey ML, Heflin LJ, Alberto P. The Use of Social Stories to Promote Independent Behaviors in Novel Events for Children with PDD-NOS. Focus on Autism and Other Developmental Disabilities. Fal. 2004;19(3):164-176. X-3.
1551 JÃ¤rbrink K, McCrone P, Fombonne E, et al. Cost-impact of young adults with high-functioning autistic spectrum disorder. Research in Developmental Disabilities. 01–02. 2007;28(1):94-104. X-1, X-4. [pmid: 16551499].
1552 Jackson C. A life of his own. Ment Health Care. 02. 1998;1(6):186-7. X-10. [pmid: 9791407].
1553 Jackson HJ. Current trends in the treatment of phobias in autistic and mentally retarded persons. Australia & New Zealand Journal of Developmental Disabilities. 12. 1983;9(4):191-208. X-1, X-2, X-3, X-4, X-10.
1554 Jacobson JW. Early intensive behavioral intervention: Emergence of a consumer-driven service model. The Behavior Analyst. Fal. 2000;23(2):149-171. X-1, X-2, X-3, X-4.
1555 Jacobson JW, Ackerman LJ. Differences in adaptive functioning among people with autism or mental retardation. J Autism Dev Disord. 06. 1990;20(2):205-19. X-4, X-10. [pmid: 2347820].
1556 Jacobson L, Stenstrom I. Visually impairing ROP in children born in Sweden 1975–89. Acta Ophthalmol Suppl. 1993;(210):16-9. X-1, X-4, X-10.
1557 Jacquemont S, Hagerman RJ, Hagerman PJ, et al. Fragile-X syndrome and fragile X-associated tremor/ataxia syndrome: two faces of FMR1. Lancet Neurol. 01. 2007;6(1):45-55. X-1, X-2, X-3, X-4. [pmid: 17166801].
1558 Jahr E. Teaching children with autism to answer novel wh-questions by utilizing a multiple exemplar strategy. Res Dev Disabil. 09–10. 2001;22(5):407-23. X-3. [pmid: 11580167].
1559 Jahr E, Eikeseth S, Eldevik S, et al. Frequency and Latency of Social Interaction in an Inclusive Kindergarten Setting: A Comparison between Typical Children and Children with Autism. Autism: The International Journal of Research and Practice. 2007;11(4):349-363. X-4. [pmid: 17656399].
1560 Jahr E, Eldevik S, Eikeseth S. Teaching children with autism to initiate and sustain cooperative play. Res Dev Disabil. 03–04. 2000;21(2):151-69. X-3. [pmid: 10817421].
1561 Jambaque I, Chiron C, Dumas C, et al. Mental and behavioural outcome of infantile epilepsy treated by vigabatrin in tuberous sclerosis patients. Epilepsy Res. 02. 2000;38(2–3):151-60. X-1, X-4. [pmid: 10642043].
1562 James SJ, Cutler P, Melnyk S, et al. Metabolic biomarkers of increased oxidative stress and impaired methylation capacity in children with autism. Am J Clin Nutr. 12. 2004;80(6):1611-7. X-4. [pmid: 15585776].
1563 James SJ, Melnyk S, Fuchs G, et al. Efficacy of methylcobalamin and folinic acid treatment on glutathione redox status in children with autism. Am J Clin Nutr. 01. 2009;89(1):425-30. X-4. [pmid: 19056591].
1564 Jamieson S. Creating an Educational Program for Young Children Who Are Blind and Who Have Autism. RE:view: Rehabilitation Education for Blindness and Visual Impairment. Win. 2004;35(4):165. X-1, X-2, X-3, X-4.
1565 Jandova M, Vlcek J, Klemerova V, et al. Monitoring of TPN consumption at the University Teaching Hospital in Hradec Kralove. Pharm World Sci. 02. 1998;20(1):28-31. X-1, X-4, X-10. [pmid: 9536468].
1566 Jani SK, Pennington EC. Depth dose characteristics of 24-MV x-ray beams at extended SSD. Med Phys. 03–04. 1991;18(2):292-4. X-1, X-3, X-4, X-10. [pmid: 1904530].
1567 Janicki MP, Jacobson JW. The character of developmental disabilities in New York State: preliminary observations. Int J Rehabil Res. 06. 1982;5(2):191-202. X-4, X-10. [pmid: 7118336].
1568 Janicki MP, Jacobson JW. Selected clinical features and service characteristics of autistic adults. Psychol Rep. 04. 1983;52(2):387-90. X-1, X-4, X-10. [pmid: 6878537].
1569 Janicki MP, Lubin RA, Friedman E. Variations in characteristics and service needs of persons with autism. J Autism Dev Disord. 03. 1983;13(1):73-85. X-4, X-10. [pmid: 6602125].
1570 Jansson-Verkasalo E, Ceponiene R, Kielinen M, et al. Deficient auditory processing in children with Asperger Syndrome, as indexed by event-related potentials. Neurosci Lett. 03. 6. 2003;338(3):197-200. X-4. [pmid: 12581830].
1571 Jansson-Verkasalo E, Kujala T, Jussila K, et al. Similarities in the phenotype of the auditory neural substrate in children with Asperger syndrome and their parents. Eur J Neurosci. 08. 2005;22(4):986-90. X-4. [pmid: 16115221].
1572 Janzen-Wilde ML, Duchan JF, Higginbotham DJ. Successful use of facilitated communication with an oral child. Journal of Speech & Hearing Research. 06. 1995;38(3):658-676. X-10. [pmid: 7674658].
1573 Jarbrink K. The economic consequences of autistic spectrum disorder among children in a Swedish municipality. Autism. 09. 2007;11(5):453-63. X-4. [pmid: 17942458].
1574 Jarbrink K, Fombonne E, Knapp M. Measuring the parental, service and cost impacts of children with autistic spectrum disorder: a pilot study. J Autism Dev Disord. 08. 2003;33(4):395-402. X-4. [pmid: 12959418].
1575 Jarvinen-Pasley A, Wallace GL, Ramus F, et al. Enhanced perceptual processing of speech in autism. Dev Sci. 01. 2008;11(1):109-21. X-1, X-4. [pmid: 18171373].
1576 Jaselskis CA, Cook EH Jr, Fletcher KE, et al. Clonidine treatment of hyperactive and impulsive children with autistic disorder. J Clin Psychopharmacol. 10. 1992;12(5):322-7. X-3, X-10. [pmid: 1479049].
1577 Jasmin E, Couture M, McKinley P, et al. Sensori-motor and daily living skills of preschool children with autism spectrum disorders. J Autism Dev Disord. 02. 2009;39(2):231-41. X-4. [pmid: 18629623].
1578 Jelleyman T, Ure A. Attitudes to immunisation: a survey of health professionals in the Rotorua District. N Z Med J. 02. 20. 2004;117(1189):U769. X-1, X-4. [pmid: 15014558].
1579 Jennes-Coussens M, Magill-Evans J, Koning C. The Quality of Life of Young Men with Asperger Syndrome: A Brief Report. Autism: The International Journal of Research & Practice. 2006;10(4):403-414. X-1, X-4. [pmid: 16908482].
1580 Jennett HK, Harris SL, Mesibov GB. Commitment to philosophy, teacher efficacy, and burnout among teachers of children with autism. J Autism Dev Disord. 12. 2003;33(6):583-93. X-1, X-4. [pmid: 14714928].
1581 Jensen CC, McConnachie G, Pierson T. Long-term multicomponent intervention to reduce severe problem behavior: A 63-month evaluation. Journal of Positive Behavior Interventions. Fal. 2001;3(4):225-236. 250. X-1, X-3.
1582 Jensen PS, Youngstrom EA, Steiner H, et al. Consensus Report on Impulsive Aggression as a Symptom across Diagnostic Categories in Child Psychiatry: Implications for Medication Studies. Journal of the American Academy of Child & Adolescent Psychiatry. 03. 2007;46(3):309. X-1, X-2, X-3, X-4. [pmid: 17314717].
1583 Jenson WR, Rovner L, Cameron S, et al. Reduction of self-injurious behavior in an autistic girl using a multifaceted treatment program. J Behav Ther Exp Psychiatry. 03. 1985;16(1):77-80. X-3, X-10. [pmid: 3998179].
1584 Jepsen RH, VonThaden K. The effect of cognitive education on the performance of students with neurological developmental disabilities. NeuroRehabilitation. 2002;17(3):201-9. X-1, X-3, X-4. [pmid: 12237500].
1585 Jerome J, Frantino EP, Sturmey P. The effects of errorless learning and backward chaining on the acquisition of Internet skills in adults with developmental disabilities. J Appl Behav Anal. Spring. 2007;40(1):185-9. X-1, X-3, X-4. [pmid: 17471803].
1586 Jerome J, Sturmey P. Reinforcing efficacy of interactions with preferred and nonpreferred staff under progressive-ratio schedules. J Appl Behav Anal. Summer. 2008;41(2):221-5. X-1, X-3, X-4. [pmid: 18595285].
1587 Jesner OS, Aref-Adib M, Coren E. Risperidone for autism spectrum disorder. Cochrane Database Syst Rev. 2007;(1):CD005040. X-2.
1588 Jeste SS, Nelson CA III. Event Related Potentials in the Understanding of Autism Spectrum Disorders: An Analytical Review. Journal of Autism and Developmental Disorders. 03. 2009;39(3):495-510. X-1, X-2, X-3, X-4. [pmid: 18850262].
1589 Jocelyn LJ, Casiro OG, Beattie D, et al. Treatment of children with autism: a randomized controlled trial to evaluate a caregiver-based intervention program in community day-care centers. J Dev Behav Pediatr. 10. 1998;19(5):326-34. X-10. [pmid: 9809262].
1590 Johansson M, Billstedt E, Danielsson S, et al. Autism spectrum disorder and underlying brain mechanism in the oculoauriculovertebral spectrum. Dev Med Child Neurol. 04. 2007;49(4):280-8. X-3, X-4. [pmid: 17376139].
1591 Johnson CR, Butter EM, Handen BL, et al. Standardised Observation Analogue Procedure (SOAP) for Assessing Parent and Child Behaviours in Clinical Trials. Journal of Intellectual & Developmental Disability. 09. 2009;34(3):230-238. X-4. [pmid: 19681003].
1592 Johnson CR, Handen BL, Butter E, et al. Development of a parent training program for children with pervasive developmental disorders. Behavioral Interventions. 07. 2007;22(3):201-221. X-1, X-2, X-3, X-4.
1593 Johnson CR, Handen BL, Mayer-Costa M, et al. Eating habits and dietary status in young children with autism. Journal of Developmental and Physical Disabilities. 2008;20(5):66. X-4.
1594 Johnson DP, Penn DL, Bauer DJ, et al. Predictors of the therapeutic alliance in group therapy for individuals with treatment-resistant auditory hallucinations. Br J Clin Psychol. 06. 2008;47(Pt 2):171-83. X-1, X-4. [pmid: 17900393].
1595 Johnson E, Hastings RP. Facilitating factors and barriers to the implementation of intensive home-based behavioural intervention for young children with autism. Child Care Health Dev. 03. 2002;28(2):123-9. X-1, X-3, X-4. [pmid: 11952647].
1596 Johnson K, Johnson CR, Sahl RA. Behavioral and naltrexone treatment of self-injurious behavior. Journal of Developmental and Physical Disabilities Special Issue: Pharmacotherapy: II. 06. 1994;6(2):193-202. X-3, X-10.
1597 Johnson L, McComas J, Thompson A, et al. Obtained versus programmed reinforcement: Practical considerations in the treatment of escape-reinforced aggression. Journal of Applied Behavior Analysis. Sum. 2004;37(2):239-242. X-3. [pmid: 15293645].
1598 Johnson M, Ostlund S, Fransson G, et al. Omega-3/omega-6 fatty acids for attention deficit hyperactivity disorder: a randomized placebo-controlled trial in children and adolescents. J Atten Disord. 03. 2009;12(5):394-401. X-1, X-4. [pmid: 18448859].
1599 Johnson MH, Siddons F, Frith U, et al. Can autism be predicted on the basis of infant screening tests?. Dev Med Child Neurol. 04. 1992;34(4):316-20. X-4, X-10. [pmid: 1572517].
1600 Johnson SM, Hollander E. Evidence that eicosapentaenoic acid is effective in treating autism. J Clin Psychiatry. 07. 2003;64(7):848-9. X-1, X-2, X-3, X-4. [pmid: 12934990].
1601 Johnston S, Nelson C, Evans J, et al. The use of visual supports in teaching young children with autism spectrum disorder to initiate interactions. AAC: Augmentative and Alternative Communication. 06. 2003;19(2):86-103. X-3.
1602 Jolivette K, Gallagher PA, Morrier MJ, et al. Preventing Problem Behaviors in Young Children with Disabilities. Exceptionality. 04. 2008;16(2):78-92. X-1, X-2, X-3, X-4.
1603 Jones CD, Schwartz IS. When Asking Questions Is Not Enough: An Observational Study of Social Communication Differences in High Functioning Children with Autism. Journal of Autism and Developmental Disorders. 03. 2009;39(3):432-443. X-4. [pmid: 18784993].
1604 Jones CR, Happe F, Baird G, et al. Auditory discrimination and auditory sensory behaviours in autism spectrum disorders. Neuropsychologia. 11. 2009;47(13):2850-8. X-4. [pmid: 19545576].
1605 Jones EA. Establishing Response and Stimulus Classes for Initiating Joint Attention in Children with Autism. Research in Autism Spectrum Disorders. 04–06. 2009;3(2):375-389. X-3, X-4.
1606 Jones EA, Carr EG. Joint Attention in Children with Autism: Theory and Intervention. Focus on Autism and Other Developmental Disabilities. 03. 2004;19(1):13-26. X-1, X-2, X-3, X-4.
1607 Jones EA, Carr EG, Feeley KM. Multiple effects of joint attention intervention for children with autism. Behav Modif. 11. 2006;30(6):782-834. X-1, X-3. [pmid: 17050765].
1608 Jones EA, Feeley KM, Takacs J. Teaching spontaneous responses to young children with autism. J Appl Behav Anal. Fall. 2007;40(3):565-70. X-3. [pmid: 17970271].
1609 Jones G, Hack E. Individual budgets and direct payments: Issues, challenges and future implications for the strategic management of SEN: Policy paper 3, 6th series, April 2008: Chapter 3: Parent/carer involvement in the commissioning of services for children and young people with autism spectrum disorder in the East Midlands. Journal of Research in Special Educational Needs. 10. 2008;8(3):171-173. X-1, X-4.
1610 Jones KJ, Block ME. Including an Autistic Middle School Child in General Physical Education: A Case Study. Strategies: A Journal for Physical and Sport Educators. 03–04. 2006;19(4):13-16. X-1, X-2, X-3, X-4.
1611 Jones S, Cooper SA, Smiley E, et al. Prevalence of, and factors associated with, problem behaviors in adults with intellectual disabilities. J Nerv Ment Dis. 09. 2008;196(9):678-86. X-1, X-4. [pmid: 18791429].
1612 Jones V. “I Felt like I Did Something Good”--The Impact on Mainstream Pupils of a Peer Tutoring Programme for Children with Autism. British Journal of Special Education. 03. 2007;34(1):3-9. X-1, X-4.
1613 Jordan R. Meeting the Needs of Children with Autistic Spectrum Disorders in the Early Years. Australian Journal of Early Childhood. 09. 2004;29(3):1-7. X-1, X-2, X-3, X-4.
1614 Jordan R. Autistic Spectrum Disorders: A Challenge and a Model for Inclusion in Education. British Journal of Special Education. 03. 2008;35(1):11-15. X-1, X-2, X-3, X-4.
1615 Jose PE, Cohen DJ. The effect of unfamiliar tasks and teachers on autistic children’s negativism. J Am Acad Child Psychiatry. Winter. 1980;19(1):78-89. X-10. [pmid: 7365171].
1616 Josefi O, Ryan V. Non-Directive Play Therapy for Young Children with Autism: A Case Study. Clinical Child Psychology and Psychiatry. 10. 2004;9(4):533-551. X-3.
1617 Joshi PT, Capozzoli JA, Coyle JT. Low-dose neuroleptic therapy for children with childhood-onset pervasive developmental disorder. Am J Psychiatry. 03. 1988;145(3):335-8. X-10. [pmid: 3344846].
1618 Jou RJ, Handen BL, Hardan AY. Retrospective assessment of atomoxetine in children and adolescents with pervasive developmental disorders. J Child Adolesc Psychopharmacol. 04. 2005;15(2):325-30. X-1, X-6. [pmid: 15910217].
1619 Joyce PR. The medical model-why psychiatry is a branch of medicine. Aust N Z J Psychiatry. 12. 1980;14(4):269-78. X-1, X-2, X-3, X-4, X-10. [pmid: 6945093].
1620 Juneja M, Sharma S, Mukherjee SB. Sensitivity of the autism behavior checklist in Indian autistic children. J Dev Behav Pediatr. 01. 2010;31(1):48-9. X-4. [pmid: 20081436].
1621 Jung S, Sainato DM, Davis CA. Using High-Probability Request Sequences to Increase Social Interactions in Young Children with Autism. Journal of Early Intervention. 2008;30(3):163-187. X-3.
1622 Jurgens A, Anderson A, Moore DW. The effect of teaching PECS to a child with autism on verbal behaviour, play, and social functioning. Behaviour Change. 2009;26(1):3. X-3.
1623 Juul-Dam N, Townsend J, Courchesne E. Prenatal, perinatal, and neonatal factors in autism, pervasive developmental disorder-not otherwise specified, and the general population. Pediatrics. 04. 2001;107(4):E63. X-4. [pmid: 11335784].
1624 Jyonouchi H, Geng L, Ruby A, et al. Dysregulated Innate Immune Responses in Young Children with Autism Spectrum Disorders: Their Relationship to Gastrointestinal Symptoms and Dietary Intervention. Neuropsychobiology. 03. 2005;51(2):77-85. X-4. [pmid: 15741748].
1625 Jyonouchi H, Sun S, Itolazu N. Innate immunity associated with inflammatory responses and cytokine production against common dietary proteins in patients with autism spectrum disorder. Neuropsychobiology. 08. 2002;46(2):76-84. X-4. [pmid: 12378124].
1626 Jyonouchi H, Sun S, Le H. Proinflammatory and regulatory cytokine production associated with innate and adaptive immune responses in children with autism spectrum disorders and developmental regression. J Neuroimmunol. 11. 1. 2001;120(1–2):170-9. X-4. [pmid: 11694332].
1627 Kaderavek J, Rabidoux P. Interactive to Independent Literacy: A Model for Designing Literacy Goals for Children with Atypical Communication. Reading and Writing Quarterly. 07. 2004;20(3):237-260. X-1, X-2, X-3, X-4.
1628 Kadlec MB, Coster W, Tickle-Degnen L, et al. Qualities of caregiver-child interaction during daily activities of children born very low birth weight with and without white matter disorder. Am J Occup Ther. 01–02. 2005;59(1):57-66. X-1, X-4. [pmid: 15707124].
1629 Kahng SW, Hendrickson DJ, Vu CP. Comparison of Single and Multiple Functional Communication Training Responses for the Treatment of Problem Behavior. Journal of Applied Behavior Analysis Journal Citation. Fall. 2000;33(3):321-24. Publisher:. 2000 Pub Types: Journal Articles; Reports - Research. X-3, X-4.
1630 Kairuz T, Truter I, Hugo J, et al. Prescribing patterns of tricyclic and selective serotonin reuptake inhibitor antidepressants among a sample of adolescents and young adults. Pharmacoepidemiol Drug Saf. 07–08. 2003;12(5):379-82. X-1, X-4. [pmid: 12899111].
1631 Kaiser AP. The effects of parent-implemented enhanced milieu teaching on the social commuinication of children who have autism. Early Education and Development. 2000;11(4):423-446. X-1, X-3.
1632 Kalmanson B, Pekarsky JH. Infant-parent psychotherapy with an autistic toddler. Zero to Three. 02. 1987;7(3):1-6. X-3, X-10.
1633 Kalyva E, Avramidis E. Improving Communication between Children with Autism and Their Peers through the “Circle of Friends”: A Small-Scale Intervention Study. Journal of Applied Research in Intellectual Disabilities. 09. 2005;18(3):253-261. X-3.
1634 Kamen S, Skier J. Dental management of the autistic child. Spec Care Dentist. 01–02. 1985;5(1):20-3. X-10. [pmid: 3156428].
1635 Kamio Y, Toichi M. Memory illusion in high-functioning autism and Asperger’s disorder. J Autism Dev Disord. 05. 2007;37(5):867-76. X-2, X-4. [pmid: 17031448].
1636 Kamps D, Walker D, Maher J, et al. Academic and environmental effects of small group arrangements in classrooms for students with autism and other developmental disabilities. J Autism Dev Disord. 06. 1992;22(2):277-93. X-10. [pmid: 1624409].
1637 Kamps DM, Barbetta PM, Leonard BR, et al. Classwide peer tutoring: an integration strategy to improve reading skills and promote peer interactions among students with autism and general education peers. J Appl Behav Anal. Spring. 1994;27(1):49-61. X-3, X-10. [pmid: 8188563].
1638 Kamps DM, Dugan E, Potucek J, et al. Effects of cross-age peer tutoring networks among students with autism and general education students. Journal of Behavioral Education. 06. 1999;9(2):97-115. X-10.
1639 Kamps DM, Dugan EP, Leonard BR, et al. Enhanced small group instruction using choral responding and student interaction for children with autism and developmental disabilities. Am J Ment Retard. 07. 1994;99(1):60-73. X-10. [pmid: 7946254].
1640 Kamps DM, Leonard BR, Vernon S, et al. Teaching social skills to students with autism to increase peer interactions in an integrated first-grade classroom. J Appl Behav Anal. Summer. 1992;25(2):281-8. X-10. [pmid: 1634423].
1641 Kane A, Luiselli JK, Dearborn S, et al. Wearing a Weighted Vest as Intervention for Children with Autism/Pervasive Developmental Disorder: Behavioral Assessment of Stereotypy and Attention to Task. The Scientific Review of Mental Health Practice. Fal-Win. 2004;3(2):19-24. X-3.
1642 Kaplan H, Clopton M, Kaplan M, et al. Snoezelen multi-sensory environments: Task engagement and generalization. Research in Developmental Disabilities. 07–08. 2006;27(4):443-455. X-3. [pmid: 16122905].
1643 Kaplan M, Carmody DP, Gaydos A. Postural orientation modifications in autism in response to ambient lenses. Child Psychiatry Hum Dev. Winter. 1996;27(2):81-91. X-1, X-2, X-3, X-4, X-10. [pmid: 8936794].
1644 Kaplan M, Edelson SM, Seip JA. Behavioral changes in autistic individuals as a result of wearing ambient transitional prism lenses. Child Psychiatry Hum Dev. Fall. 1998;29(1):65-76. X-10. [pmid: 9735531].
1645 Kaplan RS, Steele AL. An analysis of music therapy program goals and outcomes for clients with diagnoses on the autism spectrum. J Music Ther. Spring. 2005;42(1):2-19. X-1. [pmid: 15839730].
1646 Kapur SO. Infantile autism: Case studies. NIMHANS Journal. 01. 1989;7(1):87-90. X-3, X-4, X-10.
1647 Karmali I, Greer RD, Nuzzolo-Gomez R, et al. Reducing Palilalia by Presenting Tact Corrections to Young Children with Autism, Analysis of Verbal Behavior Journal Citation. 2005;21:145-153. Publisher: Association for Behavior Analysis International. 1219 South Park Street, Kalamazoo, MI 49001. Tel: 269-492-9310; Fax: 269-492-9316; e-mail: mail@abainternational.org; Web site: http://www.abainternational.org/TAVB.asp. 2005 Pub Types: Journal Articles; Reports - Research. X-3.
1648 Kasa-Hendrickson C, Kluth P. “We Have to Start with Inclusion and Work It Out as We Go”: Purposeful Inclusion for Non-Verbal Students with Autism. International Journal of Whole Schooling. 10. 2005;2(1):2-14. X-1, X-3, X-4.
1649 Kasai K, Hashimoto O, Kawakubo Y, et al. Delayed automatic detection of change in speech sounds in adults with autism: a magnetoencephalographic study. Clin Neurophysiol. 07. 2005;116(7):1655-64. X-1, X-3, X-4. [pmid: 15899591].
1650 Kasari C. Assessing change in early intervention programs for children with autism. J Autism Dev Disord. 10. 2002;32(5):447-61. X-1, X-2, X-3. [pmid: 12463519].
1651 Kasari C, Chamberlain B, Bauminger N. Burack Jacob A, Charman Tony, Yirmiya Nurit, Zelazo Philip R, editors. Social emotions and social relationships: Can children with autism compensate?. The development of autism: Perspectives from theory and research. 2001:309-323. Mahwah, NJ, US. Lawrence Erlbaum Associates Publishers. xvii. 374. X-1, X-2, X-3, X-4.
1652 Kasari C, Freeman SFN, Paparella T. Early intervention in autism: Joint attention and symbolic play, Glidden, Laraine Masters. 2001:International review of research in mental retardation: Autism. 2001;(23):207-237. San Diego, CA, US. Academic Press. xiii. 312. X-1, X-2, X-3, X-4.
1653 Kashinath S, Woods J, Goldstein H. Enhancing generalized teaching strategy use in daily routines by parents of children with autism. J Speech Lang Hear Res. 06. 2006;49(3):466-85. X-3. [pmid: 16787891].
1654 Kastner JL, Gellin BG. Measles-mumps-rubella vaccine and autism: the rise (and fall?) of a hypothesis. Pediatr Ann. 07. 2001;30(7):408-15. X-1, X-2, X-3, X-4. [pmid: 11469172].
1655 Katagiri J. The effect of music and song texts on the emotional understanding of children with autism. J Music Ther. Spring. 2009;46(1):15-31. X-1. [pmid: 19256729].
1656 Kates-McElrath K, Axelrod S. Behavioral intervention for autism: A distinction Between two behavior analytic approaches. Behavior Analyst. 2006;7(2):242-252. X-1, X-2, X-3.
1657 Kato H, Usuda J, Okunaka T, et al. Basic and clinical research on photodynamic therapy at Tokyo Medical University Hospital. Lasers Surg Med. 06. 2006;38(5):371-5. X-1, X-2, X-3, X-4. [pmid: 16788919].
1658 Katz RC, Cacciapaglia H, Cabral K. Labeling bias and attitudes toward behavior modification revisited. J Behav Ther Exp Psychiatry. 03. 2000;31(1):67-72. X-1, X-4. [pmid: 10983748].
1659 Kauffmann C, Vance HB, Pumariega AJ, et al. Fluvoxamine treatment of a child with severe PDD: A single case study. Psychiatry: Interpersonal and Biological Processes. Fal. 2001;64(3):268-277. X-3.
1660 Kaur P, Chavan BS, Lata S, et al. Early intervention in developmental delay. Indian J Pediatr. 05. 2006;73(5):405-8. X-3, X-4. [pmid: 16741325].
1661 Kawatsu S, Kato T, Nagano-Saito A, et al. New insight into the analysis of 6-[18F]fluoro-L-DOPA PET dynamic data in brain tissue without an irreversible compartment: comparative study of the Patlak and Logan analyses. Radiat Med. 01–02. 2003;21(1):47-54. X-1, X-4. [pmid: 12801143].
1662 Kay BR. Bittersweet farms. J Autism Dev Disord. 09. 1990;20(3):309-21. X-1, X-2, X-3, X-4, X-10. [pmid: 2228914].
1663 Kay S, Harchik AE, Luiselli JK. Elimination of Drooling by an Adolescent Student with Autism Attending Public High School. Journal of Positive Behavior Interventions. 2006;8(1):24-28. X-1, X-3, X-4.
1664 Kayser JE, Billingsley FF, Neel RS. A comparison of in-context and traditional instructional approaches: Total task, single trial versus backward chaining, multiple trials. Journal of the Association for Persons with Severe Handicaps. Spr. 1986;11(1):28-38. X-3, X-10.
1665 Keats L. Doug: The rhythm in his world. Canadian Journal of Music Therapy. Fal. 1995;3(1):53-69. X-1, X-3, X-10.
1666 Keel JH, Mesibov GB, Woods AV. TEACCH-supported employment program. J Autism Dev Disord. 02. 1997;27(1):3-9. X-3, X-10. [pmid: 9018578].
1667 Keeling K, Myles BS, Gagnon E, et al. Using the Power Card Strategy to teach sportsmanship skills to a child with autism. Focus on Autism and Other Developmental Disabilities. Sum. 2003;18(2):105-111. X-3.
1668 Keen D. The Use of Non-Verbal Repair Strategies by Children with Autism. Research in Developmental Disabilities: A Multidisciplinary Journal. 05–06. 2005;26(3):243-254. X-3, X-4.
1669 Keen D, Brannigan KL, Cuskelly M. Toilet training for children with autism: The effects of video modeling category. Journal of Developmental and Physical Disabilities. 08. 2007;19(4):291-303. X-3.
1670 Keen D, Sigafoos J, Woodyatt G. Replacing prelinguistic behaviors with functional communication. Journal of Autism and Developmental Disorders. 2001;31(4):385-398. X-3. [pmid: 11569585].
1671 Kelley ME, Lerman DC, Van Camp CM. The effects of competing reinforcement schedules on the acquisition of functional communication. J Appl Behav Anal. Spring. 2002;35(1):59-63. X-1, X-3, X-4. [pmid: 11936546].
1672 Kelley ME, Shillingsburg MA, Castro MJ, et al. Further evaluation of emerging speech in children with developmental disabilities: training verbal behavior. J Appl Behav Anal. Fall. 2007;40(3):431-45. X-3. [pmid: 17970258].
1673 Kelly AB, Garnett MS, Attwood T, et al. Autism spectrum symptomatology in children: the impact of family and peer relationships. J Abnorm Child Psychol. 10. 2008;36(7):1069-81. X-4. [pmid: 18437549].
1674 Kelly S, Green G, Sidman M. Visual identity matching and auditory-visual matching: a procedural note. J Appl Behav Anal. Summer. 1998;31(2):237-43. X-3, X-10. [pmid: 9652102].
1675 Kemner C, Lamme VA, Kovacs I, et al. Integrity of lateral and feedbackward connections in visual processing in children with pervasive developmental disorder. Neuropsychologia. 03. 25. 2007;45(6):1293-8. X-1, X-4. [pmid: 17101159].
1676 Kemner C, Oranje B, Verbaten MN, et al. Normal P50 gating in children with autism. J Clin Psychiatry. 03. 2002;63(3):214-7. X-4. [pmid: 11926720].
1677 Kemner C, Verbaten MN, Koelega HS, et al. Are abnormal event-related potentials specific to children with ADHD? A comparison with two clinical groups. Percept Mot Skills. 12. 1998;87(3 Pt 1):1083-90. X-4, X-10. [pmid: 9885081].
1678 Kemner C, Willemsen-Swinkels SH, de Jonge M, et al. Open-label study of olanzapine in children with pervasive developmental disorder. J Clin Psychopharmacol. 10. 2002;22(5):455-60. X-3. [pmid: 12352267].
1679 Kemp DC, Carr EG. Reduction of severe problem behavior in community employment using an hypothesis-driven multicomponent intervention approach. Journal of the Association for Persons with Severe Handicaps. Win. 1995;20(4):229-247. X-1, X-3, X-10.
1680 Kennedy CH. Manipulating antecedent conditions to alter the stimulus control of problem behavior. J Appl Behav Anal. Spring. 1994;27(1):161-70. X-3, X-10. [pmid: 8188556].
1681 Kennedy CH, Haring TG. Combining reward and escape DRO to reduce the problem behavior of students with severe disabilities. Journal of the Association for Persons with Severe Handicaps. Sum. 1993;18(2):85-92. X-1, X-3, X-10.
1682 Kennedy CH, Juarez AP, Becker A, et al. Children with severe developmental disabilities and behavioral disorders have increased special healthcare needs. Dev Med Child Neurol. 12. 2007;49(12):926-30. X-4. [pmid: 18039240].
1683 Kenny MC, Winick CB. An integrative approach to play therapy with an autistic girl. International Journal of Play Therapy. 2000;9(1):11-33. X-3.
1684 Kerby DS, Dawson BL. Autistic features, personality, and adaptive behavior in males with the fragile X syndrome and no autism. Am J Ment Retard. 01. 1994;98(4):455-62. X-1, X-4, X-10. [pmid: 8148122].
1685 Keret D, Bassett GS, Bunnell WP, et al. Scoliosis in Rett syndrome. J Pediatr Orthop. 03–04. 1988;8(2):138-42. X-1, X-4, X-10. [pmid: 3350946].
1686 Kern JK, Garver CR, Grannemann BD, et al. Response to vestibular sensory events in autism. Research in Autism Spectrum Disorders. 01–03. 2007;1(1):67-74. X-4.
1687 Kern JK, Van Miller S, Evans PA, et al. Efficacy of porcine secretin in children with autism and pervasive developmental disorder. J Autism Dev Disord. 06. 2002;32(3):153-60. X-3. [pmid: 12108616].
1688 Kern L, Bailin D, Mauk JE. Effects of a topical anesthetic on non-socially maintained self-injurious behavior. Developmental Medicine & Child Neurology. 11. 2003;45(11):769-771. X-3, X-4. [pmid: 14580133].
1689 Kern L, Carberry N, Haidara C. Analysis and intervention with two topographies of challenging behavior exhibited by a young woman with autism. Research in Developmental Disabilities. 07–08. 1997;18(4):275-287. X-1, X-3, X-10. [pmid: 9216027].
1690 Kern L, Koegel RL, Dunlap G. The influence of vigorous versus mild exercise on autistic stereotyped behaviors. J Autism Dev Disord. 03. 1984;14(1):57-67. X-10. [pmid: 6706897].
1691 Kern L, Koegel RL, Dyer K, et al. The effects of physical exercise on self-stimulation and appropriate responding in autistic children. J Autism Dev Disord. 12. 1982;12(4):399-419. X-3, X-10. [pmid: 7161239].
1692 Kern L, Starosta K, Adelman BE. Reducing pica by teaching children to exchange inedible items for edibles. Behav Modif. 03. 2006;30(2):135-58. X-3. [pmid: 16464843].
1693 Kern P, Aldridge D. Using embedded music therapy interventions to support outdoor play of young children with autism in an inclusive community-based child care program. J Music Ther. Winter. 2006;43(4):270-94. X-3. [pmid: 17348756].
1694 Kern P, Wakeford L, Aldridge D. Improving the performance of a young child with autism during self-care tasks using embedded song interventions: A case study. Music Therapy Perspectives. 2007;25(1):43-51. X-3.
1695 Kern P, Wolery M, Aldridge D. Use of songs to promote independence in morning greeting routines for young children with autism. J Autism Dev Disord. 08. 2007;37(7):1264-71. X-3. [pmid: 17120150].
1696 Kerrin RG, Murdock JY, Sharpton WR, et al. Who’s doing the pointing? Investigating facilitated communication in a classroom setting with students with autism. Focus on Autism and Other Developmental Disabilities. Sum. 1998;13(2):73-79. X-10.
1697 Kerth DM, Progar PR, Morales S. The Effects of Non-Contingent Self-Restraint on Self-Injury. Journal of Applied Research in Intellectual Disabilities. 03. 2009;22(2):187-193. X-1, X-3.
1698 Keselyak NT, Simmer-Beck M, Bray KK, et al. Evaluation of an academic service-learning course on special needs patients for dental hygiene students: a qualitative study. J Dent Educ. 03. 2007;71(3):378-92. X-1, X-4. [pmid: 17389573].
1699 Kezuka E. The role of touch in facilitated communication. Journal of Autism and Developmental Disorders. 10. 1997;27(5):571-593. X-10. [pmid: 9403373].
1700 Khalfa S, Bruneau N, Roge B, et al. Increased perception of loudness in autism. Hear Res. 12. 2004;198(1–2):87-92. X-4. [pmid: 15617227].
1701 Kielinen M, Hjelmquist E, Moilanen I, et al. Intervention, treatment and care in autistic disorder. Challenging case reports from northern Finland. Int J Circumpolar Health. 02. 2005;64(1):65-76. X-3, X-4. [pmid: 15776994].
1702 Kielinen M, Linna SL, Moilanen I. Some aspects of treatment and habilitation of children and adolescents with autistic disorder in Northern-Finland. Int J Circumpolar Health. 2002;61(Suppl 2):69-79. X-1. [pmid: 12585822].
1703 Kielinen M, Rantala H, Timonen E, et al. Associated medical disorders and disabilities in children with autistic disorder: a population-based study. Autism. 03. 2004;8(1):49-60. X-1, X-2, X-3. [pmid: 15070547].
1704 Kientz MA, Dunn W. A comparison of the performance of children with and without autism on the Sensory Profile. Am J Occup Ther. 07–08. 1997;51(7):530-7. X-4, X-10. [pmid: 9242859].
1705 Kiernan C. The use of nonvocal communication techniques with autistic individuals. J Child Psychol Psychiatry. 07. 1983;24(3):339-75. X-1, X-2, X-3, X-4, X-10. [pmid: 6874783].
1706 Kiernan C, Reid B. The use of augmentative communication systems in schools and units for autistic and aphasic children in the United Kingdom. Br J Disord Commun. 04. 1984;19(1):47-61. X-10. [pmid: 6733032].
1707 Kilchenstein MW, Schuerholz L. Autistic defenses and the impairment of cognitive development. Bull Menninger Clin. Fall. 1995;59(4):443-59. X-3, X-4, X-10. [pmid: 8535384].
1708 Killion SW, McCarthy SM. Part I: assessment. Hospitalization of the autistic child. MCN Am J Matern Child Nurs. 11–12. 1980;5(6):413-7. X-2, X-4, X-10. [pmid: 6776376].
1709 Killoran I, Tymon D, Frempong G. Disabilities and Inclusive Practices within Toronto Preschools. International Journal of Inclusive Education. 01. 2007;11(1):81-95. X-1, X-4.
1710 Kim S-Y, Yun J. Determining Daily Physical Activity Levels of Youth with Developmental Disabilities: Days of Monitoring Required?. Adapted Physical Activity Quarterly. 07. 2009;26(3):220-235. X-4. [pmid: 19799095].
1711 Kim YS, Kumar S. Cross-cultural Examination of Social Interactions During a One-week Dousa-hou (Japanese Psychorehabilitation) Camp. Psychological Reports. 12. 2004;95(3,Part1):1050-1054. X-1, X-4. [pmid: 15666954].
1712 Kimball JW, Kinney EM, Taylor BA, et al. Video Enhanced Activity Schedules for Children with Autism: A Promising Package for Teaching Social Skills. Education & Treatment of Children. 08. 2004;27(3):280-298. X-3.
1713 King B, Zwi K, Nunn K, et al. Use of risperidone in a paediatric population: an observational study. J Paediatr Child Health. 09–10. 2003;39(7):523-7. X-1, X-4. [pmid: 12969207].
1714 King BH. Pharmacological treatment of mood disturbances, aggression, and self-injury in persons with pervasive developmental disorders. J Autism Dev Disord. 10. 2000;30(5):439-45. X-1, X-2, X-3. [pmid: 11098881].
1715 King BH, Davanzo P. Buspirone treatment of aggression and self-injury in autistic and nonautistic persons with severe mental retardation. Developmental Brain Dysfunction. 01–02. 1996;90(1):22-31. X-1, X-10.
1716 King GA, Zwaigenbaum L, King S, et al. A qualitative investigation of changes in the belief systems of families of children with autism or Down syndrome. Child Care Health Dev. 05. 2006;32(3):353-69. X-4. [pmid: 16634980].
1717 King MJ, Valdovinos MG. Social Validity of Behavioral Practices in the Treatment of Autism--A Review of the “Super Nanny”. Research in Autism Spectrum Disorders. 01. 2009;3(1):173-178. X-1, X-4.
1718 Kinnell HG. “Addiction” to a strait jacket: A case report of treatment of self-injurious behaviour in an autistic child. Journal of Mental Deficiency Research. 03. 1984;28(1):77-79. X-1, X-3, X-4, X-10. [pmid: 6716459].
1719 Kistner J, Robbins F, Haskett M. Assessment and skill remediation of hyperlexic children. J Autism Dev Disord. 06. 1988;18(2):191-205. X-1, X-3, X-4, X-10. [pmid: 3410810].
1720 Kitayama M, Wada-Isoe K, Nakaso K, et al. Clinical evaluation of Parkinson’s disease dementia: association with aging and visual hallucination. Acta Neurol Scand. 09. 2007;116(3):190-5. X-1, X-4. [pmid: 17714333].
1721 Klaeger D, McDougle CJ. Secretin in autism--A parent’s perspective. Journal of Autism and Developmental Disorders. 02. 2000;30(1):72-73. X-3. [pmid: 10819124].
1722 Klauber T. The significance of trauma in work with the parents of severely disturbed children, and its implications for work with parents in general. Journal of Child Psychotherapy. 04. 1998;24(1):85-107. X-1, X-2, X-3, X-4, X-10.
1723 Klecan-Aker JS, Gill C. Teaching language organization to a child with pervasive developmental disorder: A case study. Child Language Teaching & Therapy. 02. 2005;21(1):60-74. X-3.
1724 Klein S. Autistic phenomena in neurotic patients. International Journal of PsychoAnalysis. 1980;61(3):395-402. X-10. [pmid: 7440079].
1725 Klein U, Nowak AJ. Characteristics of patients with autistic disorder (AD) presenting for dental treatment: a survey and chart review. Spec Care Dentist. 09–10. 1999;19(5):200-7. X-4, X-10. [pmid: 10765886].
1726 Kleinman JM, Ventola PE, Pandey J, et al. Diagnostic Stability in Very Young Children with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 04. 2008;38(4):606-615. X-4. [pmid: 17924183].
1727 Klima A, Desloovere C, Lorz M. Radiosensitizing with cis-platin in advanced head and neck cancer. Results and problems. Acta Otorhinolaryngol Belg. 1989;43(3):231-8. X-1, X-4, X-10. [pmid: 2694749].
1728 Klin A. Listening p in regard to speech in four children with developmental disabilities. J Child Psychol Psychiatry. 05. 1992;33(4):763-9. X-3, X-4, X-10. [pmid: 1376327].
1729 Klin A. Attributing social meaning to ambiguous visual stimuli in higher-functioning autism and Asperger syndrome: The Social Attribution Task. J Child Psychol Psychiatry. 10. 2000;41(7):831-46. X-4. [pmid: 11079426].
1730 Klin A, Danovitch JH, Merz AB, et al. Circumscribed Interests in Higher Functioning Individuals with Autism Spectrum Disorders: An Exploratory Study. Research and Practice for Persons with Severe Disabilities (RPSD). 2007;32(2):89-100. X-4.
1731 Klin A, Lin DJ, Gorrindo P, et al. Two-year-olds with autism orient to non-social contingencies rather than biological motion. Nature. 05. 14. 2009;459(7244):257-61. X-4. [pmid: 19329996].
1732 Klin A, Saulnier CA, Sparrow SS, et al. Social and Communication Abilities and Disabilities in Higher Functioning Individuals with Autism Spectrum Disorders: The Vineland and the ADOS. Journal of Autism and Developmental Disorders. 04. 2007;37(4):748-759. X-4. [pmid: 17146708].
1733 Klin A, Volkmar FR. Asperger syndrome. Child Adolesc Psychiatr Clin N Am. 01. 2003;12(1):xiii-xvi. X-1, X-2, X-3, X-4. [pmid: 12512394].
1734 Klykylo WM, et al. Clinical effects of fenfluramine in ten autistic subjects. Journal of Autism and Developmental Disorders. 12. 1985;15(4):417-423. X-10. [pmid: 4077816].
1735 Knabe R, Bovier P. Pharmacological treatment of extreme self-injurious behavior in autism. European Psychiatry. 1992;7(6):297-298. X-1, X-3, X-10.
1736 Knabe R, Schulz P, Richard J. Initial aggravation of self-injurious behavior in autistic patients receiving naltrexone treatment. Journal of Autism and Developmental Disorders. 12. 1990;20(4):591-593. X-1, X-2, X-3, X-10. [pmid: 2279977].
1737 Knapp M, Romeo R, Beecham J. Economic cost of autism in the UK. Autism. 05. 2009;13(3):317-36. X-1, X-2, X-3, X-4. [pmid: 19369391].
1738 Knivsberg AM, Reichelt KL, Hoien T, et al. A randomised, controlled study of dietary intervention in autistic syndromes. Nutr Neurosci. 09. 2002;5(4):251-61. X-3. [pmid: 12168688].
1739 Knivsberg A-M, Reichelt K-L, HÃ¸ien T, et al. Effect of a Dietary Intervention on Autistic Behavior. Focus on Autism and Other Developmental Disabilities. Win. 2003;18(4):247-256. X-3.
1740 Knivsberg A-M, Wiig K, Lind G, et al. Dietary intervention in autistic syndromes. Brain Dysfunction. 11–12. 1990;3(5–6):315-327. X-10.
1741 Knoester M, Helmerhorst FM, van der Westerlaken LA, et al. Matched follow-up study of 5 8-year-old ICSI singletons: child behaviour, parenting stress and child (health-related) quality of life. Hum Reprod. 12. 2007;22(12):3098-107. X-3, X-4. [pmid: 17905745].
1742 Knott F, Dunlop A-W, Mackay T. Living with ASD: How Do Children and Their Parents Assess Their Difficulties with Social Interaction and Understanding?. Autism: The International Journal of Research & Practice. 2006;10(6):609-617. X-4. [pmid: 17088276].
1743 Kobayahi R. Affective communication of infants with autistic spectrum disorder and internal representation of their mothers. Psychiatry and Clinical Neurosciences. 04. 2000;54(2):235-243. X-3. [pmid: 10803821].
1744 Kobayashi R, Murata T, Yoshinaga K. A follow-up study of 201 children with autism in Kyushu and Yamaguchi areas, Japan. J Autism Dev Disord. 09. 1992;22(3):395-411. X-1, X-10. [pmid: 1383189].
1745 Kodak T, Lerman DC, Volkert VM, et al. Further examination of factors that influence preference for positive versus negative reinforcement. J Appl Behav Anal. Spring. 2007;40(1):25-44. X-3. [pmid: 17471792].
1746 Kodak T, Miltenberger RG, Romaniuk C. The effects of differential negative reinforcement of other behavior and noncontingent escape on compliance. J Appl Behav Anal. Fall. 2003;36(3):379-82. X-3. [pmid: 14596581].
1747 Kodak T, Northup J, Kelley ME. An evaluation of the types of attention that maintain problem behavior. J Appl Behav Anal. Spring. 2007;40(1):167-71. X-3, X-4. [pmid: 17471800].
1748 Koegel LK. Interventions to facilitate communication in autism. J Autism Dev Disord. 10. 2000;30(5):383-91. X-2. [pmid: 11098873].
1749 Koegel LK, Camarata SM, Valdez-Menchaca M, et al. Setting generalization of question-asking by children with autism. American Journal on Mental Retardation. 01. 1998;102(4):346-357. X-10. [pmid: 9475943].
1750 Koegel LK, Carter CM, Koegel RL. Teaching children with autism self-initiations as a pivotal response. Topics in Language Disorders. 04–06. 2003;23(2):134-145. X-3.
1751 Koegel LK, Koegel RL, Frea W, et al. Priming as a method of coordinating educational services for students with autism. Language, Speech, and Hearing Services in Schools. 07. 2003;34(3):228-235. X-3.
1752 Koegel LK, Koegel RL, Hurley C, et al. Improving social skills and disruptive behavior in children with autism through self-management. J Appl Behav Anal. Summer. 1992;25(2):341-53. X-10. [pmid: 1634427].
1753 Koegel LK, Koegel RL, Nefdt N, et al. First S.T.E.P.: A Model for the Early Identification of Children with Autism Spectrum Disorders. Journal of Positive Behavior Interventions. 2005;7(4):247-252. X-1, X-2, X-3, X-4.
1754 Koegel LK, Koegel RL, Shoshan Y, et al. Pivotal response intervention II: Preliminary long-term outcomes data. Journal of the Association for Persons with Severe Handicaps. Fal. 1999;24(3):186-198. X-10.
1755 Koegel LK, Stiebel D, Koegel RL. Reducing aggression in children with autism toward infant or toddler siblings. Journal of the Association for Persons with Severe Handicaps. Sum. 1998;23(2):111-118. X-10.
1756 Koegel RL. Social Development in Individuals with High Functioning Autism and Asperger Disorder. Research and Practice for Persons with Severe Disabilities (RPSD). Sum. 2007;32(2):140-141. X-1, X-2, X-3, X-4.
1757 Koegel RL, Bimbela A, Schreibman L. Collateral effects of parent training on family interactions. J Autism Dev Disord. 06. 1996;26(3):347-59. X-10. [pmid: 8792265].
1758 Koegel RL, Camarata S, Koegel LK, et al. Increasing speech intelligibility in children with autism. J Autism Dev Disord. 06. 1998;28(3):241-51. X-10. [pmid: 9656136].
1759 Koegel RL, Dunlap G, Dyer K. Intertrial interval duration and learning in autistic children. J Appl Behav Anal. Spring. 1980;13(1):91-9. X-10. [pmid: 7364701].
1760 Koegel RL, Egel AL, Williams JA. Behavioral contrast and generalization across settings in the treatment of autistic children. J Exp Child Psychol. 12. 1980;30(3):422-37. X-10. [pmid: 7205139].
1761 Koegel RL, Frea WD. Treatment of social behavior in autism through the modification of pivotal social skills. Journal of Applied Behavior Analysis. Fal. 1993;26(3):369-377. X-1, X-3, X-10. [pmid: 8407685].
1762 Koegel RL, Koegel LK. Extended reductions in stereotypic behavior of students with autism through a self-management treatment package. J Appl Behav Anal. Spring. 1990;23(1):119-27. X-10. [pmid: 2335483].
1763 Koegel RL, Koegel LK, Surratt A. Language intervention and disruptive behavior in preschool children with autism. J Autism Dev Disord. 06. 1992;22(2):141-53. X-10. [pmid: 1378049].
1764 Koegel RL, O’Dell M, Dunlap G. Producing speech use in nonverbal autistic children by reinforcing attempts. J Autism Dev Disord. 12. 1988;18(4):525-38. X-10. [pmid: 3215880].
1765 Koegel RL, O’Dell MC, Koegel LK. A natural language teaching paradigm for nonverbal autistic children. J Autism Dev Disord. 06. 1987;17(2):187-200. X-10. [pmid: 3610995].
1766 Koegel RL, Openden D, Koegel LK. A systematic desensitization paradigm to treat hypersensitivity to auditory stimuli in children with autism in family contexts. Research and Practice for Persons with Severe Disabilities. Special Issue: Family and Disability. Sum. 2004;29(2):122-134. X-3.
1767 Koegel RL, Schreibman L, Loos LM, et al. Consistent stress profiles in mothers of children with autism. J Autism Dev Disord. 06. 1992;22(2):205-16. X-1, X-4, X-10. [pmid: 1624405].
1768 Koegel RL, Shirotova L, Koegel LK. Brief report: using individualized orienting cues to facilitate first-word acquisition in non-responders with autism. J Autism Dev Disord. 11. 2009;39(11):1587-92. X-3, X-4. [pmid: 19488847].
1769 Koegel RL, Symon JB, Kern Koegel L. Parent education for families of children with autism living in geographically distant areas. Journal of Positive Behavior Interventions. Spr. 2002;4(2):88-103. X-3.
1770 Koegel RL, Vernon TW, Koegel LK. Improving social initiations in young children with autism using reinforcers with embedded social interactions. J Autism Dev Disord. 09. 2009;39(9):1240-51. X-3. [pmid: 19357942].
1771 Koegel RL, Werner GA, Vismara LA, et al. The Effectiveness of Contextually Supported Play Date Interactions between Children with Autism and Typically Developing Peers. Research and Practice for Persons with Severe Disabilities (RPSD). Sum. 2005;30(2):93-102. X-3.
1772 Koegel RL, Williams JA. Direct versus indirect response-reinforcer relationships in teaching autistic children. J Abnorm Child Psychol. 12. 1980;8(4):537-47. X-3, X-10. [pmid: 7462531].
1773 Koenig KP, Bleiweiss J, Brennan S, et al. The ASD Nest Program: A Model for Inclusive Public Education for Students with Autism Spectrum Disorders. TEACHING Exceptional Children. 09–10. 2009;42(1):6-13. X-1, X-2, X-3, X-4.
1774 Kogan MD, Strickland BB, Blumberg SJ, et al. A national profile of the health care experiences and family impact of autism spectrum disorder among children in the United States, 2005–2006. Pediatrics. 12. 2008;122(6):e1149-58. X-4. [pmid: 19047216].
1775 Kohen-Raz R. Application of tetra-ataxiametric posturography in clinical and developmental diagnosis. Percept Mot Skills. 10. 1991;73(2):635-56. X-4, X-10. [pmid: 1766798].
1776 Kohen-Raz R, Volkmar FR, Cohen DJ. Postural control in children with autism. J Autism Dev Disord. 09. 1992;22(3):419-32. X-4, X-10. [pmid: 1383190].
1777 Kohler FW. Examining the services received by young children with autism and their families: A survey of parent responses. Focus on Autism and Other Developmental Disabilities. Fal. 1999;14(3):150-158. X-10.
1778 Kohler FW, Greteman C, Raschke D, et al. Using a Buddy Skills Package to Increase the Social Interactions between a Preschooler with Autism and Her Peers. Topics in Early Childhood Special Education. Fall. 2007;27(3):155-163. X-3.
1779 Kohler FW, Strain PS, Hoyson M, et al. Using a group-oriented contingency to increase social interactions between children with autism and their peers. A preliminary analysis of corollary supportive behaviors. Behav Modif. 01. 1995;19(1):10-32. X-3. [pmid: 7880156].
1780 Kohler FW, Strain PS, Maretsky S, et al. Promoting positive and supportive interactions between preschoolers: An analysis of group-oriented contingencies. Journal of Early Intervention. Fal. 1990;14(4):327-341. X-3, X-10.
1781 Kohler FW, Strain PS, Shearer DD. The overtures of preschool social skill intervention agents. Differential rates, forms, and functions. Behav Modif. 10. 1992;16(4):525-42. X-1, X-3, X-4, X-10. [pmid: 1417712].
1782 Kohler JA, Shortland G, Rolles CJ. Effect of fenfluramine on autistic symptoms. Br Med J (Clin Res Ed). 10. 10. 1987;295(6603):885. X-10.
1783 Kok AJ, Kong TY, Bernard-Opitz V. A comparison of the effects of structured play and facilitated play approaches on preschoolers with autism. A case study. Autism. 06. 2002;6(2):181-96. X-3. [pmid: 12083284].
1784 Kokina A, Kern L. Social Story Interventions for Students with Autism Spectrum Disorders: A Meta-Analysis. J Autism Dev Disord. 2010. 01. 7. X-2, X-3.
1785 Kokkinos CM, Davazoglou AM. Special Education Teachers under Stress: Evidence from a Greek National Study. Educational Psychology. 07. 2009;29(4):407-424. X-1, X-3, X-4.
1786 Kokubun M, Haishi K, Okuzumi H, et al. Factors affecting age of walking by children with mental retardation. Percept Mot Skills. 04. 1995;80(2):547-52. X-10. [pmid: 7675588].
1787 Kolakowska T, Gadhvi H, Molyneux S. An open clinical trial of fenfluramine in chronic schizophrenia: a pilot study. Int Clin Psychopharmacol. 01. 1987;2(1):83-8. X-10. [pmid: 2889761].
1788 Kolevzon A, Mathewson KA, Hollander E. Selective serotonin reuptake inhibitors in autism: a review of efficacy and tolerability. J Clin Psychiatry. 03. 2006;67(3):407-14. X-1, X-2, X-3, X-4. [pmid: 16649827].
1789 Kolmen BK, Feldman HM, Handen BL, et al. Naltrexone in young autistic children: a double-blind, placebo-controlled crossover study. J Am Acad Child Adolesc Psychiatry. 02. 1995;34(2):223-31. X-10. [pmid: 7896655].
1790 Kolmen BK, Feldman HM, Handen BL, et al. Naltrexone in young autistic children: replication study and learning measures. J Am Acad Child Adolesc Psychiatry. 11. 1997;36(11):1570-8. X-10. [pmid: 9394942].
1791 Komori H, Matsuishi T, Yamada S, et al. Cerebrospinal fluid biopterin and biogenic amine metabolites during oral R-THBP therapy for infantile autism. J Autism Dev Disord. 04. 1995;25(2):183-93. X-10. [pmid: 7559284].
1792 Komoto J, Usui S, Hirata J. Infantile autism and affective disorder. Journal of Autism and Developmental Disorders. 03. 1984;14(1):81-84. X-1, X-3, X-10. [pmid: 6706898].
1793 Konno Y. Modification of physiological and behavioral responsivity to auditory stimuli with the progress of Dohsa-method training in children with autism. Japanese Journal of Special Education. 03. 2001;38(6):65-81. X-3.
1794 Konstantareas M, Homatidis S, Cesaroni L. Brief report: variables related to parental choice to medicate their autistic children. J Autism Dev Disord. 08. 1995;25(4):443-52. X-10. [pmid: 7592254].
1795 Konstantareas MM. Autistic children exposed to simultaneous communication training: a follow-up. J Autism Dev Disord. 03. 1987;17(1):115-31. X-10. [pmid: 3571136].
1796 Konstantareas MM, Gravelle G. Facilitated communication. Autism. 12. 1998;2(4):389-414. X-10.
1797 Konstantareas MM, Homatidis S, Plowright CM. Assessing resources and stress in parents of severely dysfunctional children through the Clarke modification of Holroyd’s Questionnaire on Resources and Stress. J Autism Dev Disord. 06. 1992;22(2):217-34. X-1, X-4, X-10. [pmid: 1624406].
1798 Koristkova B, Grundmann M, Brozmanova H. Differences between prescribed daily doses and defined daily doses of antiepileptics--therapeutic drug monitoring as a marker of the quality of the treatment. Int J Clin Pharmacol Ther. 09. 2006;44(9):438-42. X-1, X-2, X-3, X-4. [pmid: 16995332].
1799 Koristkova B, Sjoqvist F, Grundmann M, et al. The use of TDM data to assess the validity of defined daily doses of antiepileptics: a comparison between a Czech and Swedish University Hospital. Ther Drug Monit. 10. 2006;28(5):589-93. X-1, X-2, X-3, X-4. [pmid: 17038870].
1800 Korpilahti P, Jansson-Verkasalo E, Mattila ML, et al. Processing of affective speech prosody is impaired in Asperger syndrome. J Autism Dev Disord. 09. 2007;37(8):1539-49. X-4. [pmid: 17086440].
1801 Kortebein P, Bopp MM, Granger CV, et al. Outcomes of inpatient rehabilitation for older adults with debility. Am J Phys Med Rehabil. 02. 2008;87(2):118-25. X-1. [pmid: 17912135].
1802 Koshes RJ, Rock NL. Use of clonidine for behavioral control in an adult patient with autism. American Journal of Psychiatry. 11. 1994;151(11):1714. X-1, X-3, X-10.
1803 Kottorp A, Bernspang B, Fisher AG. Validity of a performance assessment of activities of daily living for people with developmental disabilities. J Intellect Disabil Res. 11. 2003;47(Pt 8):597-605. X-4. [pmid: 14641807].
1804 Kouijzer MEJ, de Moor JMH, Gerrits BJL, et al. Neurofeedback Improves Executive Functioning in Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 01. 2009;3(1):145-162. X-3.
1805 Kouri TA. Effects of simultaneous communication in a child-directed treatment approach with preschoolers with severe disabilities. AAC: Augmentative and Alternative Communication. 12. 1988;4(4):222-232. X-10.
1806 Kowalski E, Lieberman LJ, Daggett S. Getting Involved in the IEP Process. Journal of Physical Education, Recreation & Dance. 09. 2006;77(7):35-39. X-1, X-2, X-3, X-4.
1807 Kozima H, Nakagawa C, Yasuda Y. Children-robot interaction: a pilot study in autism therapy. Prog Brain Res. 2007;164:385-400. X-3. [pmid: 17920443].
1808 Krabe R, Bovier P. Norepinephrine antidepressants may increase self-injurious behavior in autistic syndromes. European Psychiatry. 1994;9(6):309-311. X-3, X-10.
1809 Kraemer BR, Cook CR, Browning-Wright D, et al. Effects of training on the use of the Behavior Support Plan Quality Evaluation Guide with autism educators. A preliminary investigation examining positive behavior support plans. Journal of Positive Behavior Interventions. 07. 2008;10(3):179-189. X-1, X-4.
1810 Kramer DA. The autistic moment in psychotherapy. Contemporary Family Therapy: An International Journal. Special Issue: Contemporary family therapy. Spr-Sum. 1987;9(1–2):79-89. X-2, X-3, X-4, X-10.
1811 Kramer DA, Anderson RB, Westman JC. The corrective autistic experience: An application of the models of Tinbergen and Mahler. Child Psychiatry & Human Development. Win. 1984;15(2):104-120. X-10. [pmid: 6534639].
1812 Kramer-Marek G, Serpa C, Szurko A, et al. Spectroscopic properties and photodynamic effects of new lipophilic porphyrin derivatives: efficacy, localisation and cell death pathways. J Photochem Photobiol B. 07. 3. 2006;84(1):1-14. X-1, X-3, X-4. [pmid: 16495073].
1813 Krantz PJ. Commentary: interventions to facilitate socialization. J Autism Dev Disord. 10. 2000;30(5):411-3. X-2. [pmid: 11098876].
1814 Krantz PJ, et al. Teaching complex language to autistic children. Analysis & Intervention in Developmental Disabilities. 1981;1(3–4):259-297. X-10.
1815 Krantz PJ, MacDuff MT, McClannahan LE. Programming participation in family activities for children with autism: parents’ use of photographic activity schedules. J Appl Behav Anal. Spring. 1993;26(1):137-8. X-3, X-10. [pmid: 8473254].
1816 Krantz PJ, McClannahan LE. Teaching children with autism to initiate to peers: effects of a script-fading procedure. J Appl Behav Anal. Spring. 1993;26(1):121-32. X-3, X-10. [pmid: 8473251].
1817 Krantz PJ, McClannahan LE. Social interaction skills for children with autism: a script-fading procedure for beginning readers. J Appl Behav Anal. Summer. 1998;31(2):191-202. X-3, X-10. [pmid: 9652099].
1818 Krasny L, Williams BJ, Provencal S, et al. Social skills interventions for the autism spectrum: essential ingredients and a model curriculum. Child Adolesc Psychiatr Clin N Am. 01. 2003;12(1):107-22. X-1, X-2, X-3, X-4. [pmid: 12512401].
1819 Kratochvil CJ, Findling RL, McDougle CJ, et al. Pharmacological Management of Agitation and Aggression in an Adolescent with Autism. Journal of the American Academy of Child and Adolescent Psychiatry. 08. 2005;44(8):829. X-1, X-2, X-3. [pmid: 16034286].
1820 Krauss MW, Gulley S, Sciegaj M, et al. Access to specialty medical care for children with mental retardation, autism, and other special health care needs. Ment Retard. 10. 2003;41(5):329-39. X-4. [pmid: 12962535].
1821 Krauss MW, Seltzer MM, Jacobson HT. Adults with autism living at home or in non-family settings: positive and negative aspects of residential status. J Intellect Disabil Res. 02. 2005;49(Pt 2):111-24. X-1, X-4. [pmid: 15634320].
1822 Kravits TR, Kamps DM, Kemmerer K, et al. Brief report: Increasing communication skills for an elementary-aged student with autism using the picture exchange communication system. Journal of Autism and Developmental Disorders. 06. 2002;32(3):225-230. X-3. [pmid: 12108624].
1823 Krishnamurthy V. A clinical experience of autism in India. J Dev Behav Pediatr. 08. 2008;29(4):331-3. X-1, X-2, X-3, X-4. [pmid: 18698197].
1824 Kroeger KA, Nelson WM III. A Language Programme to Increase the Verbal Production of a Child Dually Diagnosed with Down Syndrome and Autism. Journal of Intellectual Disability Research. 02. 2006;50(2):101-108. X-3. [pmid: 16403199].
1825 Kroon M, Groeneveld AB, Smulders YM. Cardiac output measurement by pulse dye densitometry: comparison with pulmonary artery thermodilution in post-cardiac surgery patients. J Clin Monit Comput. 12. 2005;19(6):395-9. X-1, X-4. [pmid: 16437290].
1826 Kuban KC, O’Shea TM, Allred EN, et al. Positive screening on the Modified Checklist for Autism in Toddlers (M-CHAT) in extremely low gestational age newborns. J Pediatr. 04. 2009;154(4):535-540. e1. X-4. [pmid: 19185317].
1827 Kubina RM Jr, Yurich KKL. Developing Behavioral Fluency for Students with Autism: A Guide for Parents and Teachers. Intervention in School and Clinic. 2009;44(3):131-138. X-1, X-2, X-3, X-4.
1828 Kuhn DE, DeLeon IG, Fisher WW, et al. Clarifying an ambiguous functional analysis with matched and mismatched extinction procedures. J Appl Behav Anal. Spring. 1999;32(1):99-102. X-10. [pmid: 10201106].
1829 Kuhn DE, Hardesty SL, Sweeney NM. Assessment and treatment of excessive straightening and destructive behavior in an adolescent diagnosed with autism. Journal of Applied Behavior Analysis. Sum. 2009;42(2):355-360. X-1, X-3, X-4. [pmid: 19949524].
1830 Kuhn JC, Carter AS. Maternal self-efficacy and associated parenting cognitions among mothers of children with autism. Am J Orthopsychiatry. 10. 2006;76(4):564-75. X-1, X-4. [pmid: 17209724].
1831 Kuhn SA, Lerman DC, Vorndran CM, et al. Analysis of factors that affect responding in a two-response chain in children with developmental disabilities. J Appl Behav Anal. Fall. 2006;39(3):263-80. X-3. [pmid: 17020209].
1832 Kujala T, Aho E, Lepisto T, et al. Atypical pattern of discriminating sound features in adults with Asperger syndrome as reflected by the mismatch negativity. Biol Psychol. 04. 2007;75(1):109-14. X-1, X-4. [pmid: 17257732].
1833 Kumandas S, Ã‡aksen Hs, Ã‡iftÃ§i A, et al. Lamotrigine in two cases of Rett syndrome. Brain & Development. 07. 2001;23(4):240-242. X-1. [pmid: 11377003].
1834 Kumar S, Alexander M, Gnanamuthu C. Recent experience with Rett syndrome at a tertiary care center. Neurol India. 12. 2004;52(4):494-5. X-1, X-3, X-4. [pmid: 15626843].
1835 Kumar S, Kim YS, Oh KS. Development of a social interaction questionnaire for the trainers and mothers of children with disabilities participating in Dousa-hou (Japanese psycho-rehabilitation) camps. Psychol Rep. 10. 2006;99(2):591-8. X-1, X-2, X-3, X-4. [pmid: 17153831].
1836 Kuoch H, Mirenda P. Social Story Interventions for Young Children with Autism Spectrum Disorders. Focus on Autism and Other Developmental Disabilities. Win. 2003;18(4):219-227. X-3.
1837 Kuriyama S, Kamiyama M, Watanabe M, et al. Pyridoxine treatment in a subgroup of children with pervasive developmental disorders. Dev Med Child Neurol. 04. 2002;44(4):284-6. X-1, X-3.
1838 Kurt O, Tekin-Iftar E. A comparison of constant time delay and simultaneous prompting within embedded instruction on teaching leisure skills to children with autism. Topics in Early Childhood Special Education. 05. 2008;28(1):53-64. X-3.
1839 Kusaga A, Yamashita Y, Koeda T, et al. Increased urine phenylethylamine after methylphenidate treatment in children with ADHD. Ann Neurol. 09. 2002;52(3):372-4. X-1. [pmid: 12205654].
1840 Kuttler S, Myles BS, Carlson JK. The use of social stories to reduce precursors to tantrum behavior in a student with autism. Focus on Autism and Other Developmental Disabilities. Fal. 1998;13(3):176-182. X-10.
1841 Kvinsberg A-M, Reichelt KL, NÃ¸dland M, et al. Autistic syndromes and diet: A follow-up study. Scandinavian Journal of Educational Research. 09. 1995;39(3):223-236. X-10.
1842 Lacava PG, Golan O, Baron-Cohen S, et al. Using Assistive Technology to Teach Emotion Recognition to Students With Asperger Syndrome: A Pilot Study. Remedial and Special Education. 05–06. 2007;28(3):174-181. X-3.
1843 Ladd MV, Luiselli JK, Baker L. Continuous Access to Competing Stimulation as Intervention for Self-Injurious Skin Picking in a Child with Autism. Child & Family Behavior Therapy. 2009;31(1):54-60. X-3.
1844 Laita P, Cifuentes A, Doll A, et al. Antipsychotic-related abnormal involuntary movements and metabolic and endocrine side effects in children and adolescents. J Child Adolesc Psychopharmacol. 08. 2007;17(4):487-502. X-1, X-4. [pmid: 17822343].
1845 Lalli JS, Mace FC, Wohn T, et al. Identification and modification of a response-class hierarchy. Journal of Applied Behavior Analysis. Win. 1995;28(4):551-559. X-1, X-3, X-10. [pmid: 16795881].
1846 Lam MK, Rao N. Developing a Chinese version of the psychoeducational profile (CPEP) to assess autistic children in Hong Kong. J Autism Dev Disord. 06. 1993;23(2):273-9. X-4, X-10. [pmid: 8331048].
1847 Lammers MW, Hekster YA, Keyser A, et al. Monotherapy or polytherapy for epilepsy revisited: a quantitative assessment. Epilepsia. 05. 1995;36(5):440-6. X-1, X-4, X-10. [pmid: 7614920].
1848 Lammers MW, Hekster YA, Keyser A, et al. Neither dosage nor serum levels of antiepileptic drugs are predictive for efficacy and adverse effects. Pharm World Sci. 11. 24. 1995;17(6):201-6. X-1, X-4, X-10. [pmid: 8597777].
1849 Lancioni GE. Using pictorial representations as communication means with low-functioning children. J Autism Dev Disord. 03. 1983;13(1):87-105. X-3, X-10. [pmid: 6853441].
1850 Lancioni GE, Markus S, Behrendt M. A portable vibratory-feedback device for reducing excessive vocal loudness: A case study. Behavioural and Cognitive Psychotherapy. 10. 1998;26(4):371-376. X-1, X-3, X-10.
1851 Lane R, He Y, Morris C, et al. BuChE-K and APOE epsilon4 allele frequencies in Lewy body dementias, and influence of genotype and hyperhomocysteinemia on cognitive decline. Mov Disord. 02. 15. 2009;24(3):392-400. X-1, X-2, X-3, X-4. [pmid: 19006190].
1852 Lang R, O’Reilly M, Lancioni G, et al. Discrepancy in Functional Analysis Results across Two Settings: Implications for Intervention Design. Journal of Applied Behavior Analysis. Sum. 2009;42(2):393-397. X-4. [pmid: 19949530].
1853 Lang R, O’Reilly M, Machalicek W, et al. A Preliminary Comparison of Functional Analysis Results when Conducted in Contrived versus Natural Settings. Journal of Applied Behavior Analysis. Fall. 2008;41(3):441-445. X-3. [pmid: 18816984].
1854 Lang R, Regester A, Lauderdale S, et al. Treatment of anxiety in autism spectrum disorders using cognitive behaviour therapy: A systematic review. Dev Neurorehabil. 10. 2010;13(1):53-63. X-1, X-2, X-3. [pmid: 20067346].
1855 Lang R, Shogren KA, Machalicek W, et al. Video Self-Modeling to Teach Classroom Rules to Two Students with Asperger’s. Research in Autism Spectrum Disorders. 04–06. 2009;3(2):483-488. X-3.
1856 Langdon NA, Carr EG, Owen-Deschryver JS. Functional analysis of precursors for serious problem behavior and related intervention. Behav Modif. 11. 2008;32(6):804-27. X-3. [pmid: 18456900].
1857 Langmack K, Mehta R, Twyman P, et al. Topical photodynamic therapy at low fluence rates--theory and practice. J Photochem Photobiol B. 04. 2001;60(1):37-43. X-1, X-4. [pmid: 11386679].
1858 Langsjoen H, Langsjoen P, Willis R, et al. Usefulness of coenzyme Q10 in clinical cardiology: a long-term study. Mol Aspects Med. 1994;15(Suppl):s165-75. X-1, X-2, X-3, X-4, X-10. [pmid: 7752828].
1859 Langstrom N, Grann M, Ruchkin V, et al. Risk factors for violent offending in autism spectrum disorder: a national study of hospitalized individuals. J Interpers Violence. 08. 2009;24(8):1358-70. X-4. [pmid: 18701743].
1860 Langworthy-Lam KS, Aman MG, Van Bourgondien ME. Prevalence and patterns of use of psychoactive medicines in individuals with autism in the Autism Society of North Carolina. J Child Adolesc Psychopharmacol. Winter. 2002;12(4):311-21. X-1, X-3, X-4. [pmid: 12625991].
1861 Lanovaz MJ, Fletcher SE, Rapp JT. Identifying stimuli that alter immediate and subsequent levels of vocal stereotypy: a further analysis of functionally matched stimulation. Behav Modif. 09. 2009;33(5):682-704. X-3, X-4. [pmid: 19864321].
1862 Lanquetot R. The effectiveness of peer modeling with autistic children. Journal of the Multihandicapped Person. 03. 1989;2(1):25-34. X-10.
1863 Lanter E, Watson LR. Promoting Literacy in Students with ASD: The Basics for the SLP. Language, Speech, and Hearing Services in Schools. 01. 2008;39(1):33-43. X-1, X-2, X-3, X-4.
1864 Lanyado M. Asymbolic and symbolic play: Developmental perspectives in the treatment of disturbed children. Journal of Child Psychotherapy. 1987;13(2):33-44. X-3, X-4, X-10.
1865 LaPerchia P. Behavioral disorders, learning disabilities and megavitamin therapy. Adolescence. Fall. 1987;22(87):729-38. X-1, X-2, X-3, X-4, X-10. [pmid: 2963502].
1866 Larkin AS, Gurry S. Brief report: progress reported in three children with autism using daily life therapy. J Autism Dev Disord. 08. 1998;28(4):339-42. X-10. [pmid: 9711491].
1867 Larsen FW, Mouridsen SE. The outcome in children with childhood autism and Asperger syndrome originally diagnosed as psychotic. A 30-year follow-up study of subjects hospitalized as children. Eur Child Adolesc Psychiatry. 12. 1997;6(4):181-90. X-1, X-10. [pmid: 9442996].
1868 Lasater MW, Brady MP. Effects of video self-modeling and feedback on task fluency: A home-based intervention. Education and Treatment of Children. 11. 1995;18(4):389-407. X-10.
1869 Laski KE, Charlop MH, Schreibman L. Training parents to use the natural language paradigm to increase their autistic children’s speech. J Appl Behav Anal. Winter. 1988;21(4):391-400. X-3, X-10. [pmid: 3225256].
1870 Latif A, Heinz P, Cook R. Iron deficiency in autism and Asperger syndrome. Autism. 03. 2002;6(1):103-14. X-4. [pmid: 11918106].
1871 Lattimore LP, Parsons MB, Reid DH. A prework assessment of task preference among adults with autism beginning a supported job. Journal of Applied Behavior Analysis. Spr. 2002;35(1):85-88. X-1, X-3. [pmid: 11936551].
1872 Lattimore LP, Parsons MB, Reid DH. A prework assessment of task p among adults with autism beginning a supported job. J Appl Behav Anal. Spring. 2002;35(1):85-8. X-1, X-3, X-4. [pmid: 11936551].
1873 Lattimore LP, Parsons MB, Reid DH. Assessing preferred work among adults with autism beginning supported jobs: Identification of constant and alternating task p. Behavioral Interventions. 07. 2003;18(3):161-177. X-1, X-4.
1874 Lattimore LP, Parsons MB, Reid DH. Enhancing job-site training of supported workers with autism: a reemphasis on simulation. J Appl Behav Anal. Spring. 2006;39(1):91-102. X-1, X-3. [pmid: 16602388].
1875 Laugeson EA, Frankel F, Mogil C, et al. Parent-Assisted Social Skills Training to Improve Friendships in Teens with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 04. 2009;39(4):596-606. X-1. [pmid: 19015968].
1876 Lauritsen MB, Mors O, Mortensen PB, et al. Medical disorders among inpatients with autism in Denmark according to ICD-8: a nationwide register-based study. J Autism Dev Disord. 04. 2002;32(2):115-9. X-4. [pmid: 12058839].
1877 Laushey KM, Heflin LJ. Enhancing social skills of kindergarten children with autism through the training of multiple peers as tutors. J Autism Dev Disord. 06. 2000;30(3):183-93. X-3. [pmid: 11055455].
1878 Laushey KM, Heflin LJ, Shippen M, et al. Concept Mastery Routines to Teach Social Skills to Elementary Children with High Functioning Autism. Journal of Autism and Developmental Disorders. 10. 2009;39(10):1435-1448. X-3. [pmid: 19472042].
1879 Lavie T, Sturmey P. Training staff to conduct a paired-stimulus preference assessment. J Appl Behav Anal. Summer. 2002;35(2):209-11. X-1, X-4. [pmid: 12102143].
1880 Lawer L, Brusilovskiy E, Salzer MS, et al. Use of vocational rehabilitative services among adults with autism. J Autism Dev Disord. 03. 2009;39(3):487-94. X-1, X-4. [pmid: 18810627].
1881 Lawson TR, Walsh D. The Effects of Observational Training on the Acquisition of Reinforcement for Listening. Journal of Early and Intensive Behavior Intervention. 2007;4(2):430-452. X-3, X-4.
1882 Layton TL. Language training with autistic children using four different modes of presentation. J Commun Disord. 08. 1988;21(4):333-50. X-10. [pmid: 3170784].
1883 Le Couteur A, Bailey A, Goode S, et al. A broader phenotype of autism: the clinical spectrum in twins. J Child Psychol Psychiatry. 10. 1996;37(7):785-801. X-10. [pmid: 8923222].
1884 Le Couteur A, Haden G, Hammal D, et al. Diagnosing Autism Spectrum Disorders in Pre-School Children Using Two Standardised Assessment Instruments: The ADI-R and the ADOS. Journal of Autism and Developmental Disorders. 02. 2008;38(2):362-372. X-4. [pmid: 17605097].
1885 Leach D, Duffy ML. Supporting Students with Autism Spectrum Disorders in Inclusive Settings. Intervention in School and Clinic. 2009;45(1):31-37. X-1, X-2, X-3, X-4.
1886 Leaf JB, Taubman M, Bloomfield S, et al. Increasing Social Skills and Pro-Social Behavior for Three Children Diagnosed with Autism through the Use of a Teaching Package. Research in Autism Spectrum Disorders. 01. 2009;3(1):275-289. X-3.
1887 Leask J. Vaccination and risk communication: summary of a workshop. Arlington Virginia, USA. 5–6 October 2000. J Paediatr Child Health. 04. 2002;38(2):124-8. X-1, X-2, X-3, X-4.
1888 Lebedinskaya KS, Nikolskaya OS. Brief report: analysis of autism and its treatment in modern Russian defectology. J Autism Dev Disord. 12. 1993;23(4):675-9. X-10. [pmid: 8106307].
1889 LeBlanc LA, Carr JE, Crossett SE, et al. Intensive Outpatient Behavioral Treatment of Primary Urinary Incontinence of Children With Autism. Focus on Autism and Other Developmental Disabilities. Sum. 2005;20(2):98-105. X-3.
1890 LeBlanc LA, Coates AM, Daneshvar S, et al. Using video modeling and reinforcement to teach perspective-taking skills to children with autism. J Appl Behav Anal. Summer. 2003;36(2):253-7. X-3. [pmid: 12858990].
1891 Leblanc LA, Geiger KB, Sautter RA, et al. Using the Natural Language Paradigm (NLP) to increase vocalizations of older adults with cognitive impairments. Res Dev Disabil. 07–09. 2007;28(4):437-44. X-1, X-3. [pmid: 16889934].
1892 Leblanc M-P, Ricciardi JN, Luiselli JK. Improving Discrete Trial Instruction by Paraprofessional Staff Through an Abbreviated Performance Feedback Intervention. Education and Treatment of Children. 02. 2005;28(1):76-82. X-1, X-3, X-4.
1893 Leboyer M, Bouvard MP, Launay JM, et al. Brief report: a double-blind study of naltrexone in infantile autism. J Autism Dev Disord. 06. 1992;22(2):309-19. X-3, X-10. [pmid: 1345670].
1894 Leboyer M, Bouvard MP, Lensing P, et al. Opioid excess hypothesis of autism: A double-blind study of naltrexone. Brain Dysfunction. 11–12. 1990;3(5–6):285-298. X-10.
1895 Lecavalier L, Leone S, Wiltz J. The impact of behaviour problems on caregiver stress in young people with autism spectrum disorders. J Intellect Disabil Res. 03. 2006;50(Pt 3):172-83. X-4. [pmid: 16430729].
1896 Lechago SA, Carr JE. Recommendations for reporting independent variables in outcome studies of early and intensive behavioral intervention for autism. Behav Modif. 07. 2008;32(4):489-503. X-2. [pmid: 18525063].
1897 Ledford JR, Gast DL. Feeding Problems in Children with Autism Spectrum Disorders: A Review. Focus on Autism and Other Developmental Disabilities. Fall. 2006;21(3):153-166. X-1, X-2, X-3, X-4.
1898 Ledford JR, Gast DL, Luscre D, et al. Observational and incidental learning by children with autism during small group instruction. J Autism Dev Disord. 01. 2008;38(1):86-103. X-3. [pmid: 17347879].
1899 Lee A, Duggan ES, Schuntermann P. Autistic symptoms in a 21-year-old college student: Perspectives on diagnosis and treatment. Harvard Review of Psychiatry. 03–04. 1999;6(6):313-321. X-1, X-2, X-3, X-4, X-10. [pmid: 10370438].
1900 Lee A, Hobson RP, Chiat S. I, you, me, and autism: an experimental study. J Autism Dev Disord. 04. 1994;24(2):155-76. X-4, X-10. [pmid: 8040159].
1901 Lee LC, Harrington RA, Chang JJ, et al. Increased risk of injury in children with developmental disabilities. Res Dev Disabil. 05–06. 2008;29(3):247-55. X-4. [pmid: 17582739].
1902 Lee M, Martin-Ruiz C, Graham A, et al. Nicotinic receptor abnormalities in the cerebellar cortex in autism. Brain: A Journal of Neurology. 07. 2002;125(7):1483-1495. X-1, X-3, X-4. [pmid: 12076999].
1903 Lee PC. Verification of a simple point dose calculation method for a dual energy linear accelerator with asymmetric jaws. Med Dosim. Winter. 1996;21(4):227-33. X-1, X-3, X-4, X-10. [pmid: 8985928].
1904 Lee PH, Yong SW, An YS. Changes in cerebral glucose metabolism in patients with Parkinson disease with dementia after cholinesterase inhibitor therapy. J Nucl Med. 12. 2008;49(12):2006-11. X-1, X-4. [pmid: 18997034].
1905 Lee R, Sturmey P. The effects of lag schedules and preferred materials on variable responding in students with autism. J Autism Dev Disord. 04. 2006;36(3):421-8. X-1, X-3, X-4. [pmid: 16568357].
1906 Lee S, Odom SL, Loftin R. Social Engagement with Peers and Stereotypic Behavior of Children with Autism. Journal of Positive Behavior Interventions. 2007;9(2):67-79. X-3.
1907 Lee S-H, Poston D, Poston AJ. Lessons learned through implementing a positive behavior support intervention at home: A case study on self-management with a student with autism and his mother. Education and Training in Developmental Disabilities. 12. 2007;42(4):418-427. X-3.
1908 Lee S-H, Simpson RL, Shogren KA. Effects and Implications of Self-Management for Students with Autism: A Meta-Analysis. Focus on Autism and Other Developmental Disabilities. Spr. 2007;22(1):2-13. X-1, X-2, X-3.
1909 Lee-Dukes G. Infantile autism. Am Fam Physician. 06. 1986;33(6):149-55. X-1, X-2, X-3, X-4, X-10. [pmid: 3716967].
1910 Lefebvre D, Strain PS. Effects of a group contingency on the frequency of social interactions among autistic and nonhandicapped preschool children: Making LRE efficacious. Journal of Early Intervention. Fal. 1989;13(4):329-341. X-3, X-10.
1911 LeGoff DB. Use of LEGO as a therapeutic medium for improving social competence. J Autism Dev Disord. 10. 2004;34(5):557-71. X-1. [pmid: 15628609].
1912 LeGoff DB. Use of LEGO© as a Therapeutic Medium for Improving Social Competence. Journal of Autism and Developmental Disorders. 10. 2004;34(5):557-571. X-1. [pmid: 15628609].
1913 Lehmkuhl HD, Storch EA, Bodfish JW, et al. Brief Report: Exposure and Response Prevention for Obsessive Compulsive Disorder in a 12-Year-Old with Autism. Journal of Autism and Developmental Disorders. 05. 2008;38(5):977-981. X-3. [pmid: 17885801].
1914 Leighton J, Bird G, Charman T, et al. Weak imitative performance is not due to a functional ‘mirroring’ deficit in adults with autism spectrum disorders. Neuropsychologia. 2008;46(4):1041-1049. X-1, X-4. [pmid: 18177677].
1915 Leiman M. Ogden’s matrix of transference and the concept of sign. Br J Med Psychol. 09. 2000;73(Pt 3):385-97. X-1, X-2, X-3, X-4. [pmid: 11003379].
1916 Lelord G, BarthÃ©lÃ©my C, Martineau J, et al. Free acquisition, free imitation, physiological curiosity and exchange and development therapies in autistic children. Brain Dysfunction. 11–12. 1991;4(6):335-347. X-3, X-10.
1917 Lelord G, Callaway E, Muh JP. Clinical and biological effects of high doses of vitamin B6 and magnesium on autistic children. Acta Vitaminol Enzymol. 1982;4(1–2):27-44. X-10. [pmid: 7124567].
1918 Lelord G, Muh JP, Barthelemy C, et al. Effects of pyridoxine and magnesium on autistic symptoms--initial observations. J Autism Dev Disord. 06. 1981;11(2):219-30. X-10. [pmid: 6765503].
1919 Lennox DB, Miltenberger RG, Spengler P, et al. Decelerative treatment practices with persons who have mental retardation: A review of five years of the literature. American Journal on Mental Retardation. 05. 1988;92(6):492-501. X-10. [pmid: 3285862].
1920 Lensing P, Klingler D, Lampl C, et al. Naltrexone open trial with a 5-year-old-boy. A social rebound reaction. Acta Paedopsychiatr. 1992;55(3):169-73. X-3, X-10. [pmid: 1414352].
1921 Leonard H, Nassar N, Bourke J, et al. Relation between intrauterine growth and subsequent intellectual disability in a ten-year population cohort of children in Western Australia. Am J Epidemiol. 01. 1. 2008;167(1):103-11. X-4. [pmid: 17898000].
1922 Leonard LB. Some Reflections on the Study of Children with Specific Language Impairment. Child Language Teaching and Therapy. 2009;25(2):169-171. X-1, X-2, X-3, X-4.
1923 Lepisto T, Kajander M, Vanhala R, et al. The perception of invariant speech features in children with autism. Biol Psychol. 01. 2008;77(1):25-31. X-4. [pmid: 17919805].
1924 Lepisto T, Kuitunen A, Sussman E, et al. Auditory stream segregation in children with Asperger syndrome. Biol Psychol. 12. 2009;82(3):301-7. X-4. [pmid: 19751798].
1925 Lepisto T, Kujala T, Vanhala R, et al. The discrimination of and orienting to speech and non-speech sounds in children with autism. Brain Res. 12. 20. 2005;1066(1–2):147-57. X-4. [pmid: 16325159].
1926 Lepisto T, Nieminen-von Wendt T, von Wendt L, et al. Auditory cortical change detection in adults with Asperger syndrome. Neurosci Lett. 03. 6. 2007;414(2):136-40. X-4. [pmid: 17197079].
1927 Lepisto T, Silokallio S, Nieminen-von Wendt T, et al. Auditory perception and attention as reflected by the brain event-related potentials in children with Asperger syndrome. Clin Neurophysiol. 10. 2006;117(10):2161-71. X-4. [pmid: 16890012].
1928 Lerer E, Levi S, Salomon S, et al. Association between the oxytocin receptor (OXTR) gene and autism: relationship to Vineland Adaptive Behavior Scales and cognition. Mol Psychiatry. 10. 2008;13(10):980-8. X-4. [pmid: 17893705].
1929 Lerman DC, Kelley ME, Vorndran CM, et al. Reinforcement magnitude and responding during treatment with differential reinforcement. Journal of Applied Behavior Analysis. Spr. 2002;35(1):29-48. X-1, X-3. [pmid: 11936544].
1930 Lerman DC, Kelley ME, Vorndran CM, et al. Collateral effects of response blocking during the treatment of stereotypic behavior. Journal of Applied Behavior Analysis. Spr. 2003;36(1):119-123. X-1, X-3. [pmid: 12723875].
1931 Lerman DC, Tetreault A, Hovanetz A, et al. Further evaluation of a brief, intensive teacher-training model. J Appl Behav Anal. Summer. 2008;41(2):243-8. X-1, X-3. [pmid: 18595288].
1932 Lerman DC, Vorndran C, Addison L, et al. A Rapid Assessment of Skills in Young Children with Autism. Journal of Applied Behavior Analysis. Spr. 2004;37(1):11. X-3, X-4. [pmid: 15154212].
1933 Lerman DC, Vorndran CM, Addison L, et al. Preparing Teachers in Evidence-Based Practices for Young Children with Autism. School Psychology Review. 2004;33(4):510-526. X-1, X-3, X-4.
1934 Lerner V, Miodownik C, Kaptsan A, et al. Vitamin B6 as add-on treatment in chronic schizophrenic and schizoaffective patients: a double-blind, placebo-controlled study. J Clin Psychiatry. 01. 2002;63(1):54-8. X-1, X-4. [pmid: 11838627].
1935 Leroi I, Overshott R, Byrne EJ, et al. Randomized controlled trial of memantine in dementia associated with Parkinson’s disease. Mov Disord. 06. 15. 2009;24(8):1217-21. X-1, X-3, X-4. [pmid: 19370737].
1936 Leslie DL, Martin A. Health care expenditures associated with autism spectrum disorders. Arch Pediatr Adolesc Med. 04. 2007;161(4):350-5. X-1, X-3, X-4. [pmid: 17404131].
1937 Leung JP, Wu KI. Teaching receptive naming of Chinese characters to children with autism by incorporating echolalia. J Appl Behav Anal. Spring. 1997;30(1):59-68. X-3, X-10. [pmid: 9157099].
1938 Leung J-P, Chan O-T. Teaching spontaneous verbal requests to Chinese children with autism using a time delay procedure. Bulletin of the Hong Kong Psychological Society. No. 1993:47-58. X-3, X-10.
1939 Leventhal BL, Cook EH Jr, Morford M, et al. Clinical and neurochemical effects of fenfluramine in children with autism. J Neuropsychiatry Clin Neurosci. Summer. 1993;5(3):307-15. X-10. [pmid: 8369641].
1940 Levin L, Carr EG. Food selectivity and problem behavior in children with developmental disabilities. Analysis and intervention. Behav Modif. 07. 2001;25(3):443-70. X-3. [pmid: 11428248].
1941 Levin R, Heresco-Levy U, Bachner-Melman R, et al. Association between arginine vasopressin 1a receptor (AVPR1a) promoter region polymorphisms and prepulse inhibition. Psychoneuroendocrinology. 07. 2009;34(6):901-8. X-4. [pmid: 19195791].
1942 Levine J. Controlled trials of inositol in psychiatry. Eur Neuropsychopharmacol. 05. 1997;7(2):147-55. X-1, X-10. [pmid: 9169302].
1943 Levine J, Aviram A, Holan A, et al. Inositol treatment of autism. J Neural Transm. 1997;104(2–3):307-10. X-3, X-10. [pmid: 9203092].
1944 Levine JE. Behavior management principles: Incorporating a biopsychosocial perspective. Child & Adolescent Social Work Journal. 08. 2001;18(4):253-261. X-3.
1945 Levine K, Shane HC, Wharton RH. What if...: a plea to professionals to consider the risk-benefit ratio of facilitated communication. Ment Retard. 08. 1994;32(4):300-4. discussion 314–7. X-10. [pmid: 7968563].
1946 Levinson LJ, Reid G. The effects of exercise intensity on the stereotypic behaviors of individuals with autism. Adapted Physical Activity Quarterly. 07. 1993;10(3):255-268. X-10.
1947 Levy A, Perry A. Transition of children with autism from intensive behavioural intervention programs into the school system. Journal on Developmental Disabilities. 2008;14(1):20. X-3.
1948 Levy S, Kim A-H, Olive ML. Interventions for Young Children with Autism: A Synthesis of the Literature. Focus on Autism and Other Developmental Disabilities. Spr. 2006;21(1):55-62. X-1, X-2, X-3, X-4.
1949 Levy SE, Hyman SL. Use of complementary and alternative treatments for children with autistic spectrum disorders is increasing. Pediatr Ann. 10. 2003;32(10):685-91. X-1, X-2, X-3, X-4. [pmid: 14606219].
1950 Levy SE, Hyman SL. Novel treatments for autistic spectrum disorders. Ment Retard Dev Disabil Res Rev. 2005;11(2):131-42. X-1, X-2, X-3. [pmid: 15977319].
1951 Levy SE, Mandell DS, Merhar S, et al. Use of complementary and alternative medicine among children recently diagnosed with autistic spectrum disorder. J Dev Behav Pediatr. 12. 2003;24(6):418-23. X-4. [pmid: 14671475].
1952 Levy SE, Souders MC, Ittenbach RF, et al. Relationship of dietary intake to gastrointestinal symptoms in children with autistic spectrum disorders. Biol Psychiatry. 02. 15. 2007;61(4):492-7. X-4. [pmid: 17207470].
1953 Lewis FM, Murdoch BE, Woodyatt GC. Linguistic Abilities in Children with Autism Spectrum Disorder. Research in Autism Spectrum Disorders. 01–03. 2007;1(1):85-100. X-4.
1954 Lewis JE. Are adolescents being hospitalized unnecessarily? The current use of hospitalization in psychiatric treatment. J Child Adolesc Psychiatr Ment Health Nurs. 10–12. 1989;2(4):134-8. X-1, X-2, X-3, X-4, X-10. [pmid: 2585252].
1955 Li A. Identification and Intervention for Students Who Are Visually Impaired and Who Have Autism Spectrum Disorders. TEACHING Exceptional Children. 03–04. 2009;41(4):22-32. X-1, X-2, X-3, X-4.
1956 Li XA, Ma CM, Salhani D. Measurement of percentage depth dose and lateral beam profile for kilovoltage x-ray therapy beams. Phys Med Biol. 12. 1997;42(12):2561-8. X-1, X-3, X-4, X-10. [pmid: 9434308].
1957 Li XA, Salhani D, Ma CM. Characteristics of orthovoltage x-ray therapy beams at extended SSD for applicators with end plates. Phys Med Biol. 02. 1997;42(2):357-70. X-1, X-3, X-4, X-10. [pmid: 9044418].
1958 Liakos AM, Bradley NK, Magram G, et al. Hydrocephalus and the reproductive health of women: the medical implications of maternal shunt dependency in 70 women and 138 pregnancies. Neurol Res. 01. 2000;22(1):69-88. X-1, X-3, X-4. [pmid: 10672583].
1959 Liber DB, Frea WD, Symon JBG. Using Time-Delay to Improve Social Play Skills with Peers for Children with Autism. Journal of Autism and Developmental Disorders. 02. 2008;38(2):312-323. X-3. [pmid: 17546488].
1960 Licciardello CC, Harchik AE, Luiselli JK. Social Skills Intervention for Children with Autism during Interactive Play at a Public Elementary School. Education and Treatment of Children. 2008;31(1):27-37. X-3.
1961 Liddle EB, Batty MJ, Goodman R. The Social Aptitudes Scale: an initial validation. Soc Psychiatry Psychiatr Epidemiol. 06. 2009;44(6):508-13. X-1, X-3, X-4. [pmid: 18979221].
1962 Liddle K. Implementing the picture exchange communication system (PECS). Int J Lang Commun Disord. 2001;36(Suppl):391-5. X-1. [pmid: 11340818].
1963 Lienemann J, Walker FD. Naltrexone for treatment of self-injury. American Journal of Psychiatry. 12. 1989;146(12):1639-1640. X-1, X-2, X-3, X-10.
1964 Lifter K, Ellis J, Cannon B, et al. Developmental Specificity in Targeting and Teaching Play Activities to Children with Pervasive Developmental Disorders. Journal of Early Intervention. Sum. 2005;27(4):247-267. X-3.
1965 Light JC, Roberts B, Dimarco R, et al. Augmentative and alternative communication to support receptive and expressive communication for people with autism. Journal of Communication Disorders. Special Issue: Autism: New Perspectives on Assessment and Intervention. 03–04. 1998;31(2):153-180. X-3, X-10.
1966 Lightdale JR, Hayer C, Duer A, et al. Effects of intravenous secretin on language and behavior of children with autism and gastrointestinal symptoms: a single-blinded, open-label pilot study. Pediatrics. 11. 2001;108(5):E90. X-3. [pmid: 11694674].
1967 Lilly JD, Reed D. Perceptions of Psychological Contract Violations in School Districts that Serve Children with Autism Spectrum Disorder: An Exploratory Qualitative Study. Journal of Applied School Psychology. 06. 2004;20(1):27-45. X-1, X-2, X-3, X-4.
1968 Lim SM, Kattapuram A, Lian WB. Evaluation of a Pilot Clinic-Based Social Skills Group. British Journal of Occupational Therapy. 01. 2007;70(1):35-39. X-3.
1969 Lin H, Wu DS, Wu AD. Effects of treatment distance and field size on build-up characteristics of Monte Carlo calculated absorbed dose for electron irradiation. Australas Phys Eng Sci Med. 12. 2004;27(4):219-23. X-1, X-3, X-4. [pmid: 15712590].
1970 Lin H, Wu DS, Wu AD. Effects of internal and external scatter on the build-up characteristics of Monte Carlo calculated absorbed dose for electron irradiation. Australas Phys Eng Sci Med. 09. 2005;28(3):165-71. X-1, X-3, X-4. [pmid: 16250470].
1971 Lin SY, Chu TC, Lin JP. Monte Carlo simulation of a clinical linear accelerator. Appl Radiat Isot. 12. 2001;55(6):759-65. X-1, X-4. [pmid: 11761097].
1972 Lin SY, Chu TC, Lin JP, et al. The effect of a metal hip prosthesis on the radiation dose in therapeutic photon beam irradiations. Appl Radiat Isot. 07. 2002;57(1):17-23. X-1, X-4. [pmid: 12137022].
1973 Lin SY, Lin LC, Chuang KS, et al. Comprehensive measurement for clinical dosimetry of tertiary multileaf collimator. Kaohsiung J Med Sci. 10. 2002;18(10):508-16. X-1, X-4. [pmid: 12517067].
1974 Lincoln AJ, Courchesne E, Harms L, et al. Contextual probability evaluation in autistic, receptive developmental language disorder, and control children: event-related brain potential evidence. J Autism Dev Disord. 03. 1993;23(1):37-58. X-4, X-10. [pmid: 8463201].
1975 Lincoln AJ, Courchesne E, Harms L, et al. Sensory modulation of auditory stimuli in children with autism and receptive developmental language disorder: event-related brain potential evidence. J Autism Dev Disord. 10. 1995;25(5):521-39. X-4, X-10. [pmid: 8567597].
1976 Lincoln AJ, Dickstein P, Courchesne E, et al. Auditory processing abilities in non-retarded adolescents and young adults with developmental receptive language disorder and autism. Brain Lang. 11. 1992;43(4):613-22. X-4, X-10. [pmid: 1483193].
1977 Linday LA. Oral famotidine: a potential treatment for children with autism. Med Hypotheses. 05. 1997;48(5):381-6. X-1, X-2, X-3, X-4, X-10. [pmid: 9185122].
1978 Linday LA, Tsiouris JA, Cohen IL, et al. Famotidine treatment of children with autistic spectrum disorders: pilot research using single subject research design. J Neural Transm. 2001;108(5):593-611. X-3. [pmid: 11459079].
1979 Linderman TM, Stewart KB. Sensory integrative-based occupational therapy and functional outcomes in young children with pervasive developmental disorders: A single-subject study. American Journal of Occupational Therapy. 03–04. 1999;53(2):207-213. X-10. [pmid: 10200844].
1980 Lindsay RL, Aman MG. Pharmacologic therapies aid treatment for autism. Pediatr Ann. 10. 2003;32(10):671-6. X-1, X-2, X-3, X-4. [pmid: 14606217].
1981 Lindsay RL, Eugene Arnold L, Aman MG, et al. Dietary status and impact of risperidone on nutritional balance in children with autism: a pilot study. J Intellect Dev Disabil. 12. 2006;31(4):204-9. X-4. [pmid: 17178532].
1982 Lindsay RL, Leone S, Aman MG. Discontinuation of risperidone and reversibility of weight gain in children with disruptive behavior disorders. Clin Pediatr (Phila). 06. 2004;43(5):437-44. X-1, X-3, X-4. [pmid: 15208748].
1983 Lindstrom K, Lagerroos P, Gillberg C, et al. Teenage outcome after being born at term with moderate neonatal encephalopathy. Pediatr Neurol. 10. 2006;35(4):268-74. X-1, X-4. [pmid: 16996401].
1984 Links PS, Stockwell M, Abichandani F, et al. Minor physical anomalies in childhood autism. Part I. Their relationship to pre- and perinatal complications. J Autism Dev Disord. 09. 1980;10(3):273-85. X-4, X-10. [pmid: 6927654].
1985 Linscheid TR, Hartel F, Cooley N. Are aversive procedures durable? A five year follow-up of three individuals treated with contingent electric shock. Child & Adolescent Mental Health Care. Special Issue: Aversives: II. Fal. 1993;3(2):67-76. X-1, X-3, X-4, X-10.
1986 Lionello-DeNolf KM, da Silva Barros R, McIllvane WJ. A novel method for teaching the first instances of simple discrimination to nonverbal children with autism in a laboratory environment. Psychological Record. Spr. 2008;58(2):229-244. X-3. [pmid: 19606260].
1987 Lippiello PM. Nicotinic cholinergic antagonists: a novel approach for the treatment of autism. Med Hypotheses. 2006;66(5):985-90. X-1, X-2, X-3, X-4. [pmid: 16406687].
1988 Liptak GS, Benzoni LB, Mruzek DW, et al. Disparities in diagnosis and access to health services for children with autism: Data from the National Survey of Children’s Health. Journal of Developmental & Behavioral Pediatrics. 06. 2008;29(3):152-160. X-3, X-4. [pmid: 18349708].
1989 Liptak GS, Orlando M, Yingling JT, et al. Satisfaction with primary health care received by families of children with developmental disabilities. J Pediatr Health Care. 07–08. 2006;20(4):245-52. X-4. [pmid: 16831632].
1990 Liptak GS, Stuart T, Auinger P. Health care utilization and expenditures for children with autism: data from U.S. national samples. J Autism Dev Disord. 10. 2006;36(7):871-9. X-4. [pmid: 16855879].
1991 Lisboa FL, Butterfield SA, Reif G, et al. ALT-PE by children with autism placed in regular, reversed mainstreamed, and adapted physical education classes. Percept Mot Skills. 04. 1995;80(2):553-4. X-10. [pmid: 7675589].
1992 Little L. Differences in stress and coping for mothers and fathers of children with Asperger’s syndrome and nonverbal learning disorders. Pediatr Nurs. 11–12. 2002;28(6):565-70. X-2, X-4. [pmid: 12593341].
1993 Little L, Clark RR. Wonders and worries of parenting a child with Asperger syndrome & nonverbal learning disorder. MCN Am J Matern Child Nurs. 01–02. 2006;31(1):39-44. X-1, X-4. [pmid: 16371824].
1994 Liu C, Conn K, Sarkar N, et al. Physiology-based affect recognition for computer-assisted intervention of children with Autism Spectrum Disorder. International Journal of Human-Computer Studies. 09. 2008;66(9):662-677. X-4.
1995 Lloyd H, Dallos R. Solution-focused brief therapy with families who have a child with intellectual disabilities: A description of the content of initial sessions and the processes. Clin Child Psychol Psychiatry. 07. 2006;11(3):367-86. X-1, X-3, X-4. [pmid: 17080774].
1996 Locascio JJ, Malone RP, Small AM, et al. Factors related to haloperidol response and dyskinesias in autistic children. Psychopharmacol Bull. 1991;27(2):119-26. X-1, X-2, X-3, X-4, X-10. [pmid: 1924657].
1997 Loftin RL, Odom SL, Lantz JF. Social interaction and repetitive motor behaviors. J Autism Dev Disord. 07. 2008;38(6):1124-35. X-3. [pmid: 18064552].
1998 Loguidice VA, Johnson RG, Guyer RD, et al. Anterior lumbar interbody fusion. Spine. 03. 1988;13(3):366-9. X-1, X-4, X-10. [pmid: 3291141].
1999 Lohiya GS, Tan-Figueroa L, Iannucci A. Identification of low bone mass in a developmental center: finger bone mineral density measurement in 562 residents. J Am Med Dir Assoc. 11–12. 2004;5(6):371-6. X-1, X-4. [pmid: 15530174].
2000 Loncola JA, Craig-Unkefer L. Teaching Social Communication Skills to Young Urban Children with Autism. Education and Training in Developmental Disabilities. 09. 2005;40(3):243-263. X-3.
2001 Long D. Predicting length of service provision in school-based occupational therapy. Phys Occup Ther Pediatr. 2003;23(4):79-93. X-4. [pmid: 14750310].
2002 Long ES, Hagopian LP, DeLeon IG, et al. Competing Stimuli in the Treatment of Multiply Controlled Problem Behavior during Hygiene Routines, Research in Developmental Disabilities: A Multidisciplinary Journal Journal Citation. 01–02. 2005;26(1):57-69. Publisher: Elsevier Customer Service Department. 6277 Sea Harbor Drive, Orlando, FL 32887-4800. Tel: 877-839-7126 (Toll Free); Fax: 407-363-1354; e-mail: usjcs@elsevier.com. 2005 Pub Types: Journal Articles; Reports - Research. X-3.
2003 Long K, Wood H, Holmes N. Presentation, assessment and treatment of depression in a young woman with learning disability and autism. British Journal of Learning Disabilities. 09. 2000;28(3):102-108. X-1, X-3, X-4.
2004 Longtin SE, Fabus RL. The use of videotape self-monitoring to facilitate interactive intervention in speech-language therapy with preschool children with autism. Clinical Supervisor. 2008;27(1):111-133. X-1, X-3, X-4.
2005 Loning M, Diddens H, Kupker W, et al. Laparoscopic fluorescence detection of ovarian carcinoma metastases using 5-aminolevulinic acid-induced protoporphyrin IX. Cancer. 04. 15. 2004;100(8):1650-6. X-1, X-4. [pmid: 15073853].
2006 Lonsdale D, Shamberger RJ, Audhya T. Treatment of autism spectrum children with thiamine tetrahydrofurfuryl disulfide: a pilot study. Neuro Endocrinol Lett. 08. 2002;23(4):303-8. X-4. [pmid: 12195231].
2007 Loo CY, Graham RM, Hughes CV. The caries experience and behavior of dental patients with autism spectrum disorder. J Am Dent Assoc. 11. 2008;139(11):1518-24. X-4. [pmid: 18978390].
2008 Loo CY, Graham RM, Hughes CV. Behaviour guidance in dental treatment of patients with autism spectrum disorder. Int J Paediatr Dent. 11. 2009;19(6):390-8. X-4. [pmid: 19619200].
2009 Lord C. What is melatonin? Is it a useful treatment for sleep problems in autism?. J Autism Dev Disord. 08. 1998;28(4):345-6. X-2, X-10. [pmid: 9711493].
2010 Lord C, Merrin DJ, Vest LO, et al. Communicative behavior of adults with an autistic four-year-old boy and his nonhandicapped twin brother. J Autism Dev Disord. 03. 1983;13(1):1-17. X-1, X-4, X-10. [pmid: 6853435].
2011 Lord C, Schopler E. The role of age at assessment, developmental level, and test in the stability of intelligence scores in young autistic children. Journal of Autism and Developmental Disorders. 12. 1989;19(4):483-499. X-10. [pmid: 2606880].
2012 Lord C, Schopler E. Stability of assessment results of autistic and non-autistic language-impaired children from preschool years to early school age. J Child Psychol Psychiatry. 07. 1989;30(4):575-90. X-4, X-10. [pmid: 2768359].
2013 Lord C, Wagner A, Rogers S, et al. Challenges in evaluating psychosocial interventions for Autistic Spectrum Disorders. J Autism Dev Disord. 12. 2005;35(6):695-708. discussion 709–11. X-1, X-2, X-3, X-4. [pmid: 16496206].
2014 Lorence D. Examining online chat within a domain of uncertainty: the case of Asperger’s syndrome. Health Info Libr J. 06. 2007;24(2):128-36. X-4. [pmid: 17584216].
2015 Lorimer PA, Simpson RL, Myles BS, et al. The use of social stories as a preventative behavioral intervention in a home setting with a child with autism. Journal of Positive Behavior Interventions. Win. 2002;4(1):53-60. X-3.
2016 Lounds J, Seltzer MM, Greenberg JS, et al. Transition and Change in Adolescents and Young Adults with Autism: Longitudinal Effects on Maternal Well-Being. American Journal on Mental Retardation. 11. 2007;112(6):401-417. X-1, X-4. [pmid: 17963433].
2017 Loutzenhiser L, Hadjistavropoulos H. Enhancing interprofessional patient-centered practice for children with autism spectrum disorders: a pilot project with pre-licensure health students. J Interprof Care. 08. 2008;22(4):429-31. X-1, X-3, X-4. [pmid: 18800283].
2018 Lovaas I, Newsom C, Hickman C. Self-stimulatory behavior and perceptual reinforcement. J Appl Behav Anal. Spring. 1987;20(1):45-68. X-1, X-2, X-3, X-4, X-10. [pmid: 3583964].
2019 Lovaas OI. Behavioral treatment and normal educational and intellectual functioning in young autistic children. J Consult Clin Psychol. 02. 1987;55(1):3-9. X-10. [pmid: 3571656].
2020 Lovaas OI. The development of a treatment-research project for developmentally disabled and autistic children. J Appl Behav Anal. Winter. 1993;26(4):617-30. X-10. [pmid: 8307839].
2021 Lovaas OI, Smith T, McEachin JJ. Clarifying comments on the young autism study: reply to Schopler, Short, and Mesibov. J Consult Clin Psychol. 02. 1989;57(1):165-7. X-1, X-2, X-3, X-4, X-10. [pmid: 2925969].
2022 Love JR, Carr JE, Almason SM, et al. Early and Intensive Behavioral Intervention for Autism: A Survey of Clinical Practices. Research in Autism Spectrum Disorders. 04–06. 2009;3(2):421-428. X-1, X-4.
2023 Love SR, Matson JL, West D. Mothers as effective therapists for autistic children’s phobias. J Appl Behav Anal. Fall. 1990;23(3):379-85. X-3, X-4, X-10. [pmid: 2249973].
2024 Loveland KA, Kelley ML. Development of adaptive behavior in adolescents and young adults with autism and Down syndrome. Am J Ment Retard. 07. 1988;93(1):84-92. X-1, X-3, X-4, X-10. [pmid: 2970861].
2025 Loveland KA, Kelley ML. Development of adaptive behavior in preschoolers with autism or Down syndrome. Am J Ment Retard. 07. 1991;96(1):13-20. X-4, X-10. [pmid: 1831619].
2026 Lowe K, Felce D, Perry J, et al. The characteristics and residential situations of people with severe intellectual disability and the most severe challenging behaviour in Wales. J Intellect Disabil Res. 10. 1998;42(Pt 5):375-89. X-4, X-10. [pmid: 9828069].
2027 Lowe O, Lindemann R. Assessment of the autistic patient’s dental needs and ability to undergo dental examination. ASDC J Dent Child. 01–02. 1985;52(1):29-35. X-4, X-10. [pmid: 3156901].
2028 Lowery EF. Autistic aloofness reconsidered: Case reports of two children in play therapy. Bulletin of the Menninger Clinic. 03. 1985;49(2):135-150. X-3, X-4, X-10. [pmid: 3978303].
2029 Lozzi-Toscano B. The “dance” of communication: Counseling families and children with Asperger’s syndrome. The Family Journal. 01. 2004;12(1):53-57. X-1, X-2, X-3, X-4.
2030 Lubetsky MJ, Mueller L, Madden K, et al. Family-centered/interdisciplinary team approach to working with families of children who have mental retardation. Mental Retardation. 08. 1995;33(4):251-256. X-3, X-4, X-10. [pmid: 7565148].
2031 Lubin R, Jacobson JW, Kiely M. Projected impact of the functional definition of developmental disabilities: the categorically disabled population and service eligibility. Am J Ment Defic. 07. 1982;87(1):73-9. X-1, X-4, X-10. [pmid: 6181686].
2032 Luby J, Mrakotsky C, Stalets MM, et al. Risperidone in preschool children with autistic spectrum disorders: an investigation of safety and efficacy. J Child Adolesc Psychopharmacol. 10. 2006;16(5):575-87. X-3. [pmid: 17069546].
2033 Lucarelli S, Frediani T, Zingoni AM, et al. Food allergy and infantile autism. Panminerva Med. 09. 1995;37(3):137-41. X-10. [pmid: 8869369].
2034 Luce SC, Christian WP, Anderson SR, et al. Development of a continuum of services for children and adults with autism and other severe behavior disorders. Res Dev Disabil. 1992;13(1):9-25. X-10. [pmid: 1585026].
2035 Luckett T, Bundy A, Roberts J. Do Behavioural Approaches Teach Children with Autism to Play or Are They Pretending?. Autism: The International Journal of Research and Practice. 2007;11(4):365-388. X-1, X-2, X-3, X-4. [pmid: 17656400].
2036 Lucyshyn JM, Albin RW, Horner RH, et al. Family implementation of positive behavior support for a child with autism: Longitudinal, single-case, experimental, and descriptive replication and extension. Journal of Positive Behavior Interventions. Sum. 2007;9(3):131-150. X-3.
2037 Lucyshyn JM, Irvin LK, Blumberg ER, et al. Validating the Construct of Coercion in Family Routines: Expanding the Unit of Analysis in Behavioral Assessment with Families of Children with Developmental Disabilities. Research and Practice for Persons with Severe Disabilities (RPSD). Sum. 2004;29(2):104-121. X-4.
2038 Luisell JK, Campbell S, Cannon B, et al. Assessment instruments used in the education and treatment of persons with autism: brief report of a survey of national service centers. Res Dev Disabil. 09–10. 2001;22(5):389-98. X-1, X-4. [pmid: 11580165].
2039 Luiselli JK. Case demonstration of a fading procedure to promote school attendance of a child with Asperger’s disorder. Journal of Positive Behavior Interventions. Win. 2000;2(1):47-52. X-3.
2040 Luiselli JK, Blew P, Keane J, et al. Pharamcotherapy for severe aggression in a child with autism: “Open-label” evaluation of multiple medications on response frequency and intensity of behavioral intervention. Journal of Behavior Therapy and Experimental Psychiatry. 09–12. 2000;31(3–4):219-230. X-3. [pmid: 11494958].
2041 Luiselli JK, Blew P, Thibadeau S. Therapeutic effects and long-term efficacy of antidepressant medication for persons with developmental disabilities: Behavioral assessment in two cases of treatment-resistant aggression and self-injury. Behavior Modification. 01. 2001;25(1):62-78. X-1, X-3. [pmid: 11151486].
2042 Luiselli JK, Cochran ML, Huber SA. Effects of Otitis Media on a Child with Autism Receiving Behavioral Intervention for Self-Injury. Child & Family Behavior Therapy. 2005;27(2):51-56. X-3.
2043 Luiselli JK, Kane A, Treml T, et al. Behavioral intervention to reduce physical restraint of adolescents with developmental disabilities. Behavioral Interventions. 10–12. 2000;15(4):317-330. X-1, X-3, X-4.
2044 Luiselli JK, Medeiros J, Jasinowski C, et al. Behavioral medicine treatment of ruminative vomiting and associated weight loss in an adolescent with autism. Journal of Autism and Developmental Disorders. 10. 1994;24(5):619-629. X-1, X-3, X-10. [pmid: 7814310].
2045 Luiselli JK, Ricciardi JN, Gilligan K. Liquid Fading To Establish Milk Consumption By A Child With Autism. Behavioral Interventions. 04. 2005;20(2):155-163. X-3.
2046 Luiselli JK, Ricciardi JN, Schmidt S, et al. Brief Functional Analysis and Intervention Evaluation for Treatment of Saliva-Play. Child & Family Behavior Therapy. 2004;26(3):53-61. X-3.
2047 Luiselli JK, Suskin L, McPhee DF. Continuous and intermittent application of overcorrection in a self-injurious autistic child: Alternating treatments design analysis. Journal of Behavior Therapy and Experimental Psychiatry. 12. 1981;12(4):355-358. X-10. [pmid: 7334136].
2048 Luiselli JK, Suskin L, Slocumb PR. Application of immobilization time-out in management programming with developmentally disabled children. Child & Family Behavior Therapy. Spr. 1984;6(1):1-15. X-1, X-3, X-4, X-10.
2049 Luiselli JK, Wolongevicz J, Egan P, et al. The Family Support Program: Description of a preventive, community-based behavioral intervention for children with pervasive developmental disorders. Child & Family Behavior Therapy. 1999;21(1):1-18. X-1, X-3, X-4, X-10.
2050 Luman M, Van Meel CS, Oosterlaan J, et al. Does reward frequency or magnitude drive reinforcement-learning in attention-deficit/hyperactivity disorder?. Psychiatry Res. 08. 15. 2009;168(3):222-9. X-4. [pmid: 19545907].
2051 Lund J. Treatment of psychiatric morbidity in the mentally retarded adult. Acta Psychiatr Scand. 04. 1986;73(4):429-36. X-1, X-4, X-10. [pmid: 2873716].
2052 Lundqvist L-O, Andersson G, Viding J. Effects of Vibroacoustic Music on Challenging Behaviors in Individuals with Autism and Developmental Disabilities. Research in Autism Spectrum Disorders. 04–06. 2009;3(2):390-400. X-1, X-3, X-4.
2053 Luong J, Yoder MK, Canham D. Southeast Asian parents raising a child with autism: a qualitative investigation of coping styles. J Sch Nurs. 06. 2009;25(3):222-9. X-1, X-3, X-4. [pmid: 19364878].
2054 Luscre DM, Center DB. Procedures for reducing dental fear in children with autism. J Autism Dev Disord. 10. 1996;26(5):547-56. X-3, X-4, X-10. [pmid: 8906455].
2055 Luther EH, Canham DL, Young Cureton V. Coping and social support for parents of children with autism. J Sch Nurs. 02. 2005;21(1):40-7. X-1, X-4. [pmid: 15660493].
2056 Luyster RJ, Kadlec MB, Carter A, et al. Language Assessment and Development in Toddlers with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 09. 2008;38(8):1426-1438. X-4. [pmid: 18188685].
2057 Lynch S. Intensive behavioural intervention with a 7-year-old girl with autism. Autism. 06. 1998;2(2):181-197. X-3, X-10.
2058 Ma H-H. The Effectiveness of Intervention on the Behavior of Individuals with Autism: A Meta-Analysis Using Percentage of Data Points Exceeding the Median of Baseline Phase (PEM). Behavior Modification. 2009;33(3):339-359. X-1, X-2, X-3, X-4. [pmid: 19282505].
2059 Ma YC, Nagler J, Lee MH, et al. Impact of music therapy on the communication skills of toddlers with pervasive developmental disorder. Ann N Y Acad Sci. 06. 2001;930:445-7. X-3. [pmid: 11458864].
2060 Manage P, Thibault G, BerthÃ©lÃ©my C, et al. CD4 + CD45RA + T lymphocyte deficiency in autistic children: Effect of a pyridoxine-magnesium treatment. Brain Dysfunction. 09–12. 1992;5(5–6):326-333. X-10.
2061 Maller E, Schuler A, Burton BA, et al. Meeting the vocational support needs of individuals with Asperger Syndrome and other autism spectrum disabilities. Journal of Vocational Rehabilitation. 2003;18(3):163-175. X-1, X-4.
2062 Maag JW, Rutherford RB, Wolchik SA, et al. Comparison of two short overcorrection procedures on the stereotypic behavior of autistic children. Journal of Autism and Developmental Disorders. 03. 1986;16(1):83-87. X-3, X-10. [pmid: 3957861].
2063 Maag JW, Rutherford RB, Wolchik SA, et al. Sensory extinction and overcorrection in suppressing self-stimulation: A preliminary comparison of efficacy and generalization. Education & Treatment of Children. 08. 1986;9(3):189-201. X-3, X-10.
2064 Maag JW, Wolchik SA, Rutherford RB, et al. Response covariation on self-stimulatory behaviors during sensory extinction procedures. Journal of Autism and Developmental Disorders. 06. 1986;16(2):119-132. X-3, X-10. [pmid: 3722114].
2065 MacDonald C, Jones K, Istone M. Positive Behavioral Support. Teaching Elementary Physical Education. 11. 2006;17(6):20-24. X-1, X-2, X-3, X-4.
2066 MacDonald R, Clark M, Garrigan E, et al. Using video modeling to teach pretend play to children with autism. Behavioral Interventions. 11. 2005;20(4):225-238. X-3.
2067 MacDonald R, Green G, Mansfield R, et al. Stereotypy in young children with autism and typically developing children. Res Dev Disabil. 05–06. 2007;28(3):266-77. X-4. [pmid: 16814515].
2068 MacDuff GS, Krantz PJ, McClannahan LE. Teaching children with autism to use photographic activity schedules: maintenance and generalization of complex response chains. J Appl Behav Anal. Spring. 1993;26(1):89-97. X-3, X-10. [pmid: 8473261].
2069 Mace AB, Shapiro ES, Mace FC. Effects of warning stimuli for reinforcer withdrawal and task onset on self-injury. Journal of Applied Behavior Analysis. Win. 1998;31(4):679-682. X-3, X-10. [pmid: 9891405].
2070 Mace FC, Mauro BC, Boyajian AE, et al. Effects of reinforcer quality on behavioral momentum: coordinated applied and basic research. J Appl Behav Anal. Spring. 1997;30(1):1-20. X-1, X-3, X-4, X-10. [pmid: 9157095].
2071 MacFarlane JR, Kanaya T. What Does It Mean to Be Autistic? Inter-State Variation in Special Education Criteria for Autism Services. Journal of Child and Family Studies. 12. 2009;18(6):662-669. X-1, X-2, X-3, X-4.
2072 Machalicek W, O’Reilly M, Chan JM, et al. Using Videoconferencing to Support Teachers to Conduct Preference Assessments with Students with Autism and Developmental Disabilities. Research in Autism Spectrum Disorders. 01. 2009;3(1):32-41. X-3.
2073 Machalicek W, O’Reilly MF, Beretvas N, et al. A Review of School-Based Instructional Interventions for Students with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 07–09. 2008;2(3):395-416. X-1, X-2, X-3, X-4.
2074 Machalicek W, O’Reilly MF, Beretvas N, et al. A Review of Interventions to Reduce Challenging Behavior in School Settings for Students with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 07–09. 2007;1(3):229-246. X-1, X-2, X-3, X-4.
2075 Macintosh K, Dissanayake C. Social skills and problem behaviours in school aged children with high-functioning autism and Asperger’s Disorder. J Autism Dev Disord. 11. 2006;36(8):1065-76. X-4. [pmid: 16865549].
2076 Mackay T, Knott F, Dunlop AW. Developing social interaction and understanding in individuals with autism spectrum disorder: a groupwork intervention. J Intellect Dev Disabil. 12. 2007;32(4):279-90. X-1. [pmid: 18049972].
2077 MacLean JE, Szatmari P, Jones MB, et al. Familial factors influence level of functioning in pervasive developmental disorder. J Am Acad Child Adolesc Psychiatry. 06. 1999;38(6):746-53. X-4, X-10. [pmid: 10361794].
2078 Macleod A. The Birmingham community support scheme for adults with Asperger syndrome. Autism. 06. 1999;3(2):177-192. X-1, X-3, X-4, X-10.
2079 MacLeod A, Johnston P. Standing Out and Fitting In: A Report on a Support Group for Individuals with Asperger Syndrome Using a Personal Account. British Journal of Special Education. 06. 2007;34(2):83-88. X-1, X-2, X-3, X-4.
2080 Maes B, Fryns JP, Van Walleghem M, et al. Fragile-X syndrome and autism: a prevalent association or a misinterpreted connection?. Genet Couns. 1993;4(4):245-63. X-4, X-10. [pmid: 8110411].
2081 Magiati I, Howlin P. Monitoring the progress of preschool children with autism enrolled in early intervention programmes: problems in cognitive assessment. Autism. 12. 2001;5(4):399-406. X-4. [pmid: 11777256].
2082 Magnee MJ, Oranje B, van Engeland H, et al. Cross-sensory gating in schizophrenia and autism spectrum disorder: EEG evidence for impaired brain connectivity?. Neuropsychologia. 06. 2009;47(7):1728-32. X-1, X-4. [pmid: 19397868].
2083 Magnusson AF, Gould DD. Reduction of automatically-maintained self-injury using contingent equipment removal. Behavioral Interventions. Special Issue: The treatment and assessment of the severe behavior of individuals with autism and developmental disabilities. 02. 2007;22(1):57-68. X-3, X-4.
2084 Magnusson M, Rasmussen F, Sundelin C. Early identification of children with communication disabilities--evaluation of a screening programme in a Swedish county. Acta Paediatr. 11. 1996;85(11):1319-26. X-4, X-10. [pmid: 8955459].
2085 Mahatmya D, Zobel A, Valdovinos MG. Treatment Approaches for Self-Injurious Behavior in Individuals with Autism: Behavioral and Pharmacological Methods. Journal of Early and Intensive Behavior Intervention. 2008;5(1):106-118. X-1, X-2, X-3, X-4.
2086 Mahone EM, Bridges D, Prahme C, et al. Repetitive arm and hand movements (complex motor stereotypies) in children. J Pediatr. 09. 2004;145(3):391-5. X-1, X-4. [pmid: 15343197].
2087 Mahoney G, Wheeden CA, Perales F. Relationship of preschool special education outcomes to instructional practices and parent-child interaction. Res Dev Disabil. 11–12. 2004;25(6):539-58. X-6. [pmid: 15541631].
2088 Maimburg RD, Vaeth M. Perinatal risk factors and infantile autism. Acta Psychiatr Scand. 10. 2006;114(4):257-64. X-4. [pmid: 16968363].
2089 Maimburg RD, Vaeth M. Do children born after assisted conception have less risk of developing infantile autism?. Hum Reprod. 07. 2007;22(7):1841-3. X-4. [pmid: 17456530].
2090 Maione L, Mirenda P. Effects of Video Modeling and Video Feedback on Peer-Directed Social Language Skills of a Child with Autism, Journal of Positive Behavior Interventions Journal Citation. 2006;8(2):106-118. Publisher: SAGE Publications. 2455 Teller Road, Thousand Oaks, CA 91320. Tel: 800-818-7243; Tel: 805-499-9774; Fax: 800-583-2665; e-mail: journals@sagepub.com; Web site: http://sagepub.com. 2006 Pub Types: Journal Articles; Reports - Evaluative. X-3.
2091 Makela NL, Birch PH, Friedman JM, et al. Parental perceived value of a diagnosis for intellectual disability (ID): a qualitative comparison of families with and without a diagnosis for their child’s ID. Am J Med Genet A. 11. 2009;149A(11):2393-402. X-1, X-3, X-4. [pmid: 19842198].
2092 Malandraki GA, Okalidou A. The Application of PECS in a Deaf Child with Autism: A Case Study. Focus on Autism and Other Developmental Disabilities. Spr. 2007;22(1):23-32. X-3.
2093 Malhotra S, Chakrabarti S, Gupta N, et al. High Treatment Drop-out Rate of Children with Pervasive Developmental Disorders. Hong Kong Journal of Psychiatry. 03. 2004;14(1):10-15. X-4.
2094 Malinverni G, Stasi M, Baiotto B, et al. Clinical application and dosimetric calibration procedure of the superficial and orthovoltage therapy unit Therapax DXT300. Tumori. 07–08. 2002;88(4):331-7. X-1, X-2, X-3, X-4. [pmid: 12400986].
2095 Malloy C, Yousef E. To test or not to test: parent information for discussions of food allergy and autism. Del Med J. 10. 2009;81(10):357-9. X-1, X-2, X-3, X-4. [pmid: 19999849].
2096 Malone RP, Cater J, Sheikh RM, et al. Olanzapine versus haloperidol in children with autistic disorder: an open pilot study. J Am Acad Child Adolesc Psychiatry. 08. 2001;40(8):887-94. X-3. [pmid: 11501687].
2097 Malone RP, Delaney MA, Hyman SB, et al. Ziprasidone in adolescents with autism: an open-label pilot study. J Child Adolesc Psychopharmacol. 12. 2007;17(6):779-90. X-1. [pmid: 18315450].
2098 Malone RP, Ernst M, Godfrey KA, et al. Repeated episodes of neuroleptic-related dyskinesias in autistic children. Psychopharmacology Bulletin. 1991;27(2):113-117. X-4, X-10. [pmid: 1681562].
2099 Malone RP, Maislin G, Choudhury MS, et al. Risperidone treatment in children and adolescents with autism: short- and long-term safety and effectiveness. J Am Acad Child Adolesc Psychiatry. 02. 2002;41(2):140-7. X-3. [pmid: 11837403].
2100 Mancil GR. Functional Communication Training: A Review of the Literature Related to Children with Autism. Education and Training in Developmental Disabilities. Fall. 2006;41(3):213-224. X-1, X-2, X-3, X-4.
2101 Mancil GR, Conroy MA, Haydon TF. Effects of a modified milieu therapy intervention on the social communicative behaviors of young children with autism spectrum disorders. J Autism Dev Disord. 01. 2009;39(1):149-63. X-3. [pmid: 18612805].
2102 Mancil GR, Conroy MA, Nakao T, et al. Functional Communication Training in the Natural Environment: A Pilot Investigation with a Young Child with Autism Spectrum Disorder. Education and Treatment of Children. 11. 2006;29(4):615-633. X-3.
2103 Mancina C, Tankersley M, Kamps D, et al. Reduction of inappropriate vocalizations for a child with autism using a self-management treatment program. Journal of Autism and Developmental Disorders. 12. 2000;30(6):599-606. X-3. [pmid: 11261471].
2104 Mandel DS, Walrath CM, Manteuffel B, et al. Characteristics of Children with Autistic Spectrum Disorders Served in Comprehensive Community-based Mental Health Settings. Journal of Autism and Developmental Disorders. 06. 2005;35(3):313-321. X-4. [pmid: 16119472].
2105 Mandell DS. Psychiatric hospitalization among children with autism spectrum disorders. J Autism Dev Disord. 07. 2008;38(6):1059-65. X-4. [pmid: 17975720].
2106 Mandell DS, Cao J, Ittenbach R, et al. Medicaid expenditures for children with autistic spectrum disorders: 1994 to 1999. J Autism Dev Disord. 05. 2006;36(4):475-85. X-4. [pmid: 16586155].
2107 Mandell DS, Listerud J, Levy SE, et al. Race differences in the age at diagnosis among medicaid-eligible children with autism. J Am Acad Child Adolesc Psychiatry. 12. 2002;41(12):1447-53. X-4. [pmid: 12447031].
2108 Mandell DS, Morales KH, Marcus SC, et al. Psychotropic medication use among Medicaid-enrolled children with autism spectrum disorders. Pediatrics. 03. 2008;121(3):e441-8. X-4. [pmid: 18310165].
2109 Mandell DS, Novak M. The role of culture in families’ treatment decisions for children with autism spectrum disorders. Ment Retard Dev Disabil Res Rev. 2005;11(2):110-5. X-1, X-2, X-3, X-4. [pmid: 15977313].
2110 Mandell DS, Thompson WW, Weintraub ES, et al. Trends in diagnosis rates for autism and ADHD at hospital discharge in the context of other psychiatric diagnoses. Psychiatr Serv. 01. 2005;56(1):56-62. X-3, X-4. [pmid: 15637193].
2111 Manev R, Manev H. Aminoglycoside antibiotics and autism: a speculative hypothesis. BMC Psychiatry. 2001;1:5. X-1, X-2, X-3, X-4. [pmid: 11696245].
2112 Mangus B, Henderson H, French R. Implementation of a token economy by peer tutors to increase on-task physical activity time of autistic children. Percept Mot Skills. 08. 1986;63(1):97-8. X-3, X-4, X-10. [pmid: 3748749].
2113 Manjaly ZM, Marshall JC, Stephan KE, et al. In search of the hidden: an fMRI study with implications for the study of patients with autism and with acquired brain injury. Neuroimage. 07. 2003;19(3):674-83. X-1, X-4. [pmid: 12880798].
2114 Mansell W, Morris K. A Survey of Parents’ Reactions to the Diagnosis of an Autistic Spectrum Disorder by a Local Service. Access to Information and Use of Services. Autism The International Journal of Research and Practice. 12. 2004;8(4):387-407. X-1, X-3, X-4. [pmid: 15556958].
2115 Mantis JG, Fritz CL, Marsh J, et al. Improvement in motor and exploratory behavior in Rett syndrome mice with restricted ketogenic and standard diets. Epilepsy & Behavior. 2009;15(2):61. X-1, X-4.
2116 Marc V. Beyond the archaic maternal. The Journal of Analytical Psychology. 04. 1991;36(2):231-240. X-1, X-2, X-3, X-4, X-10.
2117 Marcason W. What is the current status of research concerning use of a gluten-free, casein-free diet for children diagnosed with autism?. J Am Diet Assoc. 03. 2009;109(3):572. X-1, X-2, X-3. [pmid: 19248872].
2118 Marchant P, Hussain A, Hall K. Autistic Spectrum Disorders and Asian Children. British Journal of Educational Studies. 06. 2006;54(2):230-244. X-3, X-4.
2119 Marchetti B, Scifo R, Batticane N, et al. Immunological significance of opioid peptide dysfunction in infantile autism. Brain Dysfunction. 11–12. 1990;3(5–6):346-354. X-4, X-10.
2120 Marckel JM, Neef NA, Ferreri SJ. A preliminary analysis of teaching improvisation with the picture exchange communication system to children with autism. J Appl Behav Anal. Spring. 2006;39(1):109-15. X-3. [pmid: 16602390].
2121 Marcu I, Oppenheim D, Koren-Karie N, et al. Attachment and symbolic play in preschoolers with autism spectrum disorders. J Autism Dev Disord. 09. 2009;39(9):1321-8. X-4. [pmid: 19421849].
2122 Marcus B, Steward DJ, Khan NR, et al. Outpatient transesophageal echocardiography with intravenous propofol anesthesia in children and adolescents. J Am Soc Echocardiogr. 03–04. 1993;6(2):205-9. X-1, X-4, X-10. [pmid: 8481250].
2123 Marcus BA, Vollmer TR. Combining noncontingent reinforcement and differential reinforcement schedules as treatment for aberrant behavior. J Appl Behav Anal. Spring. 1996;29(1):43-51. X-3, X-10. [pmid: 8881343].
2124 Marder K, Tang MX, Alfaro B, et al. Postmenopausal estrogen use and Parkinson’s disease with and without dementia. Neurology. 04. 1998;50(4):1141-3. X-1, X-4, X-10. [pmid: 9566410].
2125 Margolis LH, Meisels SJ. Barriers to the effectiveness of EPSDT for children with moderate and severe developmental disabilities. Am J Orthopsychiatry. 07. 1987;57(3):424-30. X-1, X-4, X-10. [pmid: 2441606].
2126 Maria BL, Deidrick KM, Roach ES, et al. Tuberous sclerosis complex: pathogenesis, diagnosis, strategies, therapies, and future research directions. J Child Neurol. 09. 2004;19(9):632-42. X-1, X-2, X-3, X-4. [pmid: 15563008].
2127 Marin FZ. CAM versus nucleoplasty. Acta Neurochir Suppl. 2005;92:111-4. X-1, X-4. [pmid: 15830980].
2128 Marker C, Weeks M, Kraegel I. Integrating faith and treatment for children with high functioning autism spectrum disorders. Journal of Psychology and Christianity. Sum. 2007;26(2):112-121. X-1, X-2, X-3, X-4.
2129 Markle K, Clark CE 2nd. Addressing multiple systems’ failures. One agency’s approach for working with youths with autism involved in multiple service systems. Behav Healthc. 11. 2007;27(11):36-7. X-1, X-2, X-3, X-4.
2130 Marks SU. Can “Special” Programs for Children with Autism Spectrum Disorders Be Inclusive?. Research and Practice for Persons with Severe Disabilities (RPSD). Win. 2007;32(4):265-268. X-1, X-2, X-3, X-4.
2131 Maroni L. Say Hello to the Scream Extractor: Working with an Autistic Child with Psychotic Mechanisms. Journal of Child Psychotherapy. 08. 2008;34(2):222-239. X-3, X-4.
2132 Marr D, Mika H, Miraglia J, et al. The effect of sensory stories on targeted behaviors in preschool children with autism. Phys Occup Ther Pediatr. 2007;27(1):63-79. X-3.
2133 Marriage KJ, Gordon V, Brand L. A social skills group for boys with Asperger’s syndrome. Aust N Z J Psychiatry. 03. 1995;29(1):58-62. X-10. [pmid: 7625976].
2134 Marrosu F, Marrosu G, Rachel MG, et al. Paradoxical reactions elicited by diazepam in children with classic autism. Funct Neurol. 07–09. 1987;2(3):355-61. X-3, X-10. [pmid: 2826308].
2135 Marshall J, Sheller B, Mancl L, et al. Parental attitudes regarding behavior guidance of dental patients with autism. Pediatr Dent. 09–10. 2008;30(5):400-7. X-1, X-4. [pmid: 18942599].
2136 Marshall J, Sheller B, Williams BJ, et al. Cooperation predictors for dental patients with autism. Pediatr Dent. 09–10. 2007;29(5):369-76. X-4. [pmid: 18027770].
2137 Marshall JK, Mirenda P. Parent-professional collaboration for positive behavior support in the home. Focus on Autism and Other Developmental Disabilities. Win. 2002;17(4):216-228. X-1, X-2, X-3, X-4.
2138 Marteleto MR, Lima e Menezes CG, Tamanaha AC, et al. Administration of the Autism Behavior Checklist: agreement between parents and professionals’ observations in two intervention contexts. Rev Bras Psiquiatr. 09. 2008;30(3):203-8. X-1, X-4. [pmid: 18833419].
2139 Martell R. The enigma of autism. Nurs Stand. 01. 5–11. 1994;8(15):20-1. X-1, X-2, X-3, X-4, X-10.
2140 Martens BK, Houk JL. The application of Herrnstein’s law of effect to disruptive and on-task behavior of a retarded adolescent girl. Journal of the Experimental Analysis of Behavior. 01. 1989;51(1):17-27. X-1, X-3, X-4, X-10. [pmid: 2921585].
2141 Martignano A, Menegotti L, Valentini A. Monte Carlo investigation of breast intraoperative radiation therapy with metal attenuator plates. Med Phys. 12. 2007;34(12):4578-84. X-1, X-2, X-3, X-4. [pmid: 18196783].
2142 Martin A, Koenig K, Anderson GM, et al. Low-dose fluvoxamine treatment of children and adolescents with pervasive developmental disorders: a prospective, open-label study. J Autism Dev Disord. 02. 2003;33(1):77-85. X-1, X-3. [pmid: 12708582].
2143 Martin A, Landau J, Leebens P, et al. Risperidone-associated weight gain in children and adolescents: a retrospective chart review. J Child Adolesc Psychopharmacol. Winter. 2000;10(4):259-68. X-1, X-4. [pmid: 11191686].
2144 Martin A, Scahill L, Klin A, et al. Higher-functioning pervasive developmental disorders: rates and patterns of psychotropic drug use. J Am Acad Child Adolesc Psychiatry. 07. 1999;38(7):923-31. X-4, X-10. [pmid: 10405512].
2145 Martin As, Koenig K, Scahill L, et al. Open-label quetiapine in the treatment of children and adolescents with autistic disorder. Journal of Child and Adolescent Psychopharmacology. 1999;9(2):99-107. X-3, X-10. [pmid: 10461820].
2146 Martin CA, Drasgow E, Halle JW, et al. Teaching a Child with Autism and Severe Language Delays to Reject: Direct and Indirect Effects of Functional Communication Training. Educational Psychology. 04–06. 2005;25(2–3):287-304. X-3.
2147 Martin F, Farnum J. Animal-assisted therapy for children with pervasive developmental disorders. West J Nurs Res. 10. 2002;24(6):657-70. X-1. [pmid: 12365766].
2148 Martin N. Assessing Portrait Drawings Created by Children and Adolescents with Autism Spectrum Disorder. Art Therapy: Journal of the American Art Therapy Association. 2008;25(1):15-23. X-4.
2149 Martin NT, Bibby P, Mudford OC, et al. Toward the use of a standardized assessment for young children with autism: current assessment practices in the UK. Autism. 09. 2003;7(3):321-30. X-4. [pmid: 14516063].
2150 Martin SC, Wolters PL, Smith AC. Adaptive and maladaptive behavior in children with Smith-Magenis Syndrome. J Autism Dev Disord. 05. 2006;36(4):541-52. X-1, X-4. [pmid: 16570214].
2151 Martineau J, Barthelemy C, Cheliakine C, et al. Brief report: an open middle-term study of combined vitamin B6-magnesium in a subgroup of autistic children selected on their sensitivity to this treatment. J Autism Dev Disord. 09. 1988;18(3):435-47. X-10. [pmid: 3170459].
2152 Martineau J, Barthelemy C, Garreau B, et al. Vitamin B6, magnesium, and combined B6-Mg: therapeutic effects in childhood autism. Biol Psychiatry. 05. 1985;20(5):467-78. X-10. [pmid: 3886023].
2153 Martineau J, Barthelemy C, Lelord G. Long-term effects of combined vitamin Bâ‚†-magnesium administration in an autistic child. Biological Psychiatry. 1986;21(5–6):21. X-3, X-10.
2154 Martineau J, Barthelemy C, Roux S, et al. Electrophysiological effects of fenfluramine or combined vitamin Bâ‚† and magnesium on children with autistic behavior. Developmental Medicine & Child Neurology. 12. 1989;31(6):721-727. X-10. [pmid: 2599266].
2155 Martineau J, Garreau B, Barthelemy C, et al. Effects of vitamin B6 on averaged evoked potentials in infantile autism. Biol Psychiatry. 07. 1981;16(7):627-41. X-4, X-10. [pmid: 7272379].
2156 Martineau J, Garreau B, Roux S, et al. Auditory evoked responses and their modifications during conditioning paradigm in autistic children. J Autism Dev Disord. 12. 1987;17(4):525-39. X-4, X-10. [pmid: 3680154].
2157 Martineau J, Roux S, Adrien JL, et al. Electrophysiological evidence of different abilities to form cross-modal associations in children with autistic behavior. Electroencephalogr Clin Neurophysiol. 01. 1992;82(1):60-6. X-4, X-10. [pmid: 1370145].
2158 Martineau J, Roux S, Garreau B, et al. Unimodal and crossmodal reactivity in autism: presence of auditory evoked responses and effect of the repetition of auditory stimuli. Biol Psychiatry. 06. 15. 1992;31(12):1190-203. X-1, X-4, X-10. [pmid: 1391280].
2159 Martineau J, Tanguay P, Garreau B, et al. Are there sex differences in averaged evoked responses produced by coupling sound and light in children and adults?. Int J Psychophysiol. 12. 1984;2(3):177-83. X-1, X-4, X-10. [pmid: 6543360].
2160 Martineau Jl, BarthÃ©lÃ©my C, Jouve J, et al. Monoamines (serotonin and catecholamines) and their derivatives in infantile autism: Age-related changes and drug effects. Developmental Medicine & Child Neurology. 07. 1992;34(7):593-603. X-4, X-10. [pmid: 1380929].
2161 Martinez CA. Adapted Aquatics for Children with Autism. Teaching Elementary Physical Education. 09. 2006;17(5):34-36. X-1, X-2, X-3, X-4.
2162 Martins MP, Harris SL. Teaching Children with Autism to Respond to Joint Attention Initiations. Child & Family Behavior Therapy. 2006;28(1):51-68. X-3.
2163 Martos Perez J, Fortea Sevilla MS. Psychological assessment of adolescents and adults with autism. J Autism Dev Disord. 12. 1993;23(4):653-64. X-1, X-4, X-10. [pmid: 8106305].
2164 Masi G, Cosenza A, Millepiedi S, et al. Aripiprazole monotherapy in children and young adolescents with pervasive developmental disorders: a retrospective study. CNS Drugs. 2009;23(6):511-21. X-1, X-3. [pmid: 19480469].
2165 Masi G, Cosenza A, Mucci M. Prolactin levels in young children with pervasive developmental disorders during risperidone treatment. J Child Adolesc Psychopharmacol. Winter. 2001;11(4):389-94. X-3. [pmid: 11838821].
2166 Masi G, Cosenza A, Mucci M, et al. Open trial of risperidone in 24 young children with pervasive developmental disorders. J Am Acad Child Adolesc Psychiatry. 10. 2001;40(10):1206-14. X-3. [pmid: 11589534].
2167 Masi G, Cosenza A, Mucci M, et al. Risperidone monotherapy in preschool children with pervasive developmental disorders. J Child Neurol. 06. 2001;16(6):395-400. X-3. [pmid: 11417603].
2168 Mason SA, McGee GG, Farmer-Dougan V, et al. A practical strategy for ongoing reinforcer assessment. J Appl Behav Anal. Summer. 1989;22(2):171-9. X-3, X-4, X-10. [pmid: 2745238].
2169 Mason SA, Newsom CD. The application of sensory change to reduce stereotyped behavior. Res Dev Disabil. 1990;11(3):257-71. X-1, X-3, X-4, X-10. [pmid: 2399345].
2170 Massaro DW, Bosseler A. Read my lips: The importance of the face in a computer-animated tutor for vocabulary learning by children with autism. Autism. 09. 2006;10(5):495-510. X-3. [pmid: 16940315].
2171 Masse JJ, McNeil CB, Wagner SM, et al. Parent-Child Interaction Therapy and High Functioning Autism: A Conceptual Overview. Journal of Early and Intensive Behavior Intervention. 2007;4(4):714-735. X-1, X-2, X-3, X-4.
2172 Mastrangelo S. Harnessing the Power of Play: Opportunities for Children with Autism Spectrum Disorders. TEACHING Exceptional Children. 09–10. 2009;42(1):34-44. X-1, X-2, X-3, X-4.
2173 Mathai J, Bourne A, Cranswick N. Lessons learnt in conducting a clinical drug trial in children with Asperger Syndrome. Australas Psychiatry. 06. 2005;13(2):173-5. X-1, X-2, X-3, X-4. [pmid: 15948916].
2174 Matson J. Aggression and Tantrums in Children with Autism: A Review of Behavioral Treatments and Maintaining Variables. Journal of Mental Health Research in Intellectual Disabilities. 2009;2(3):169-187. X-1, X-2, X-3.
2175 Matson JL. Current Status of Differential Diagnosis for Children with Autism Spectrum Disorders. Research in Developmental Disabilities: A Multidisciplinary Journal. 03–04. 2007;28(2):109-118. X-1, X-2, X-3, X-4.
2176 Matson JL. Determining Treatment Outcome in Early Intervention Programs for Autism Spectrum Disorders: A Critical Analysis of Measurement Issues in Learning Based Interventions. Research in Developmental Disabilities: A Multidisciplinary Journal. 03–04. 2007;28(2):207-218. X-1, X-2, X-3, X-4.
2177 Matson JL, Baglio CS, Smiroldo BB, et al. Characteristics of autism as assessed by the Diagnostic Assessment for the Severely Handicapped-II (DASH-II). Res Dev Disabil. 03–04. 1996;17(2):135-43. X-4, X-10. [pmid: 8778935].
2178 Matson JL, Boisjoli JA. The Token Economy for Children with Intellectual Disability and/or Autism: A Review. Research in Developmental Disabilities: A Multidisciplinary Journal. 03–04. 2009;30(2):240-248. X-1, X-2, X-3, X-4.
2179 Matson JL, Box ML, Francis KL. Treatment of elective mute behavior in two developmentally delayed children using modeling and contingency management. Journal of Behavior Therapy and Experimental Psychiatry. 09. 1992;23(3):221-229. X-3, X-10. [pmid: 1283169].
2180 Matson JL, Compton LS, Sevin JA. Comparison and item analysis of the MESSY for autistic and normal children. Res Dev Disabil. 1991;12(4):361-9. X-4, X-10. [pmid: 1792362].
2181 Matson JL, Dempsey T. The Nature and Treatment of Compulsions, Obsessions, and Rituals in People with Developmental Disabilities. Research in Developmental Disabilities: A Multidisciplinary Journal. 05–06. 2009;30(3):603-611. X-1, X-2, X-3, X-4.
2182 Matson JL, Dempsey T, Wilkins J. Rett syndrome in adults with severe intellectual disability: exploration of behavioral characteristics. Eur Psychiatry. 09. 2008;23(6):460-5. X-4. [pmid: 18207372].
2183 Matson JL, Francis KL. Generalizing spontaneous language in developmentally delayed children via a visual cue procedure using caregivers as therapists. Behavior Modification. 04. 1994;18(2):186-197. X-10. [pmid: 8002924].
2184 Matson JL, Gardner WI, Coe DA, et al. A scale for evaluating emotional disorders in severely and profoundly mentally retarded persons. Development of the Diagnostic Assessment for the Severely Handicapped (DASH) scale. Br J Psychiatry. 09. 1991;159:404-9. X-1, X-4, X-10. [pmid: 1958951].
2185 Matson JL, Lo Vullo SV. A Review of Behavioral Treatments for Self-Injurious Behaviors of Persons with Autism Spectrum Disorders. Behavior Modification. 2008;32(1):61-76. X-1, X-2, X-3, X-4. [pmid: 18096972].
2186 Matson JL, Manikam R, Coe D, et al. Training social skills to severely mentally retarded multiply handicapped adolescents. Res Dev Disabil. 1988;9(2):195-208. X-1, X-3, X-4, X-10. [pmid: 2970102].
2187 Matson JL, Matson ML, Rivet TT. Social-Skills Treatments for Children with Autism Spectrum Disorders: An Overview. Behavior Modification. 2007;31(5):682-707. X-1, X-2, X-3, X-4. [pmid: 17699124].
2188 Matson JL, Sevin JA, Box ML, et al. An evaluation of two methods for increasing self-initiated verbalizations in autistic children. Journal of Applied Behavior Analysis. Fal. 1993;26(3):389-398. X-3, X-10. [pmid: 8407687].
2189 Matson JL, Sevin JA, Fridley D, et al. Increasing spontaneous language in three autistic children. J Appl Behav Anal. Summer. 1990;23(2):227-33. X-3, X-10. [pmid: 2373659].
2190 Matson JL, Smiroldo BB, Hastings TL. Validity of the Autism/Pervasive Developmental Disorder subscale of the Diagnostic Assessment for the Severely Handicapped-II. J Autism Dev Disord. 02. 1998;28(1):77-81. X-1, X-4, X-10. [pmid: 9546305].
2191 Matson JL, Smith KRM. Current Status of Intensive Behavioral Interventions for Young Children with Autism and PDD-NOS. Research in Autism Spectrum Disorders. 01–03. 2008;2(1):60-74. X-1, X-2, X-3, X-4.
2192 Matson JL, Taras ME, Sevin JA, et al. Teaching self-help skills to autistic and mentally retarded children. Res Dev Disabil. 1990;11(4):361-78. X-3, X-10. [pmid: 2270319].
2193 Matson JL, Wilkins J, Fodstad JC. Children with autism spectrum disorders: a comparison of those who regress vs. those who do not. Dev Neurorehabil. 10. 2010;13(1):37-45. X-4. [pmid: 20067344].
2194 Matson JL, Wilkins J, Gonzalez M. Early Identification and Diagnosis in Autism Spectrum Disorders in Young Children and Infants: How Early Is Too Early?. Research in Autism Spectrum Disorders. 01–03. 2008;2(1):75-84. X-1, X-2, X-3, X-4.
2195 Matson JL, Wilkins J, Macken J. The Relationship of Challenging Behaviors to Severity and Symptoms of Autism Spectrum Disorders. Journal of Mental Health Research in Intellectual Disabilities. 2009;2(1):29-44. X-4.
2196 Matson JL, Wilkins J, Sevin JA, et al. Reliability and Item Content of the Baby and Infant Screen for Children with aUtIsm Traits (BISCUIT): Parts 1–3. Research in Autism Spectrum Disorders. 04–06. 2009;3(2):336-344. X-1, X-2, X-3, X-4.
2197 Matsui H, Nishinaka K, Oda M, et al. Auditory event-related potentials in Parkinson’s disease: prominent correlation with attention. Parkinsonism Relat Disord. 10. 2007;13(7):394-8. X-1, X-4. [pmid: 17329143].
2198 Matthews S. Autistic children and their treatment. Health Visit. 05. 1982;55(5):242-6. X-10. [pmid: 6918379].
2199 Maurer A. The shock rod controversy. Journal of Clinical Child Psychology. Win. 1983;12(3):272-278. X-1, X-2, X-3, X-4, X-10.
2200 Mavropoulou S, Padeliadu S. Greek teachers’ perceptions of autism and implications for educational practice: A preliminary analysis. Autism. 06. 2000;4(2):173-183. X-1, X-4.
2201 Mawhood L, Howlin P. The outcome of a supported employment scheme for high-functioning adults with autism or Asperger syndrome. Autism. 09. 1999;3(3):229-254. X-1, X-4, X-10.
2202 Max ML, Burke JC. Virtual reality for autism communication and education, with lessons for medical training simulators. Stud Health Technol Inform. 1997;39:46-53. X-10. [pmid: 10184722].
2203 Mayinger B, Neumann F, Kastner C, et al. Early detection of premalignant conditions in the colon by fluorescence endoscopy using local sensitization with hexaminolevulinate. Endoscopy. 02. 2008;40(2):106-9. X-1, X-4. [pmid: 18197583].
2204 Mays RM, Gillon JE. Autism in young children: an update. J Pediatr Health Care. 01–02. 1993;7(1):17-23. X-1, X-2, X-3, X-4, X-10. [pmid: 8421239].
2205 Mazefsky CA, Goin-Kochel RP, Riley BP, et al. Genetic and environmental influences on symptom domains in twins and siblings with autism. Research in Autism Spectrum Disorders. 04–06. 2008;2(2):320-331. X-4. [pmid: 19718281].
2206 Mazefsky CA, Oswald DP. The discriminative ability and diagnostic utility of the ADOS-G, ADI-R, and GARS for children in a clinical setting. Autism. 11. 2006;10(6):533-49. X-1, X-2, X-3, X-4. [pmid: 17088271].
2207 Mazefsky CA, Williams DL, Minshew NJ. Variability in adaptive behavior in autism: evidence for the importance of family history. J Abnorm Child Psychol. 05. 2008;36(4):591-9. X-4. [pmid: 18188537].
2208 Mazzone L, Ruta L. Topiramate in children with autistic spectrum disorders. Brain Dev. 11. 2006;28(10):668. X-1, X-2, X-3, X-4. [pmid: 16797902].
2209 McAllister TW, Hays LR. TRH test, DST, and response to desipramine in primary degenerative dementia. Biol Psychiatry. 02. 1987;22(2):189-93. X-1, X-2, X-3, X-4, X-10. [pmid: 3101756].
2210 McArthur GM. Auditory processing disorders: can they be treated?. Curr Opin Neurol. 04. 2009;22(2):137-43. X-1, X-2, X-3, X-4. [pmid: 19532037].
2211 McBride JA, Panksepp J. An examination of the phenomenology and the reliability of ratings of compulsive behavior in autism. J Autism Dev Disord. 08. 1995;25(4):381-96. X-4, X-10. [pmid: 7592250].
2212 McCabe H. Parent Advocacy in the Face of Adversity: Autism and Families in the People’s Republic of China. Focus on Autism and Other Developmental Disabilities. Spr. 2007;22(1):39-50. X-1, X-2, X-3, X-4.
2213 McCabe H. The Importance of Parent-to-Parent Support among Families of Children with Autism in the People’s Republic of China. International Journal of Disability, Development and Education. 12. 2008;55(4):303-314. X-4.
2214 McCabe H. Two decades of serving children with autism in the People’s Republic of China: Achievements and challenges of a state-run mental health center. Disability & Society. 05. 2008;23(3):271-282. X-1, X-4.
2215 McCarron PA, Ma LW, Juzenas P, et al. Facilitated delivery of ALA to inaccessible regions via bioadhesive patch systems. J Environ Pathol Toxicol Oncol. 2006;25(1–2):389-402. X-1, X-2, X-3, X-4. [pmid: 16566730].
2216 McCarthy M, Hendren RL. Autism spectrum disorders have increased dramatically in prevalence in recent years. Preface. Psychiatr Clin North Am. 03. 2009;32(1):xiii-xv. X-1, X-2, X-3, X-4.
2217 McCarthy P. Childhood autism: 0–35 years. Ir Med J. 07. 1985;78(7):182-5. X-1, X-2, X-3, X-4, X-10. [pmid: 4030294].
2218 McClannahan LE, MacDuff GS, Krantz PJ. Behavior analysis and intervention for adults with autism. Behav Modif. 01. 2002;26(1):9-26. X-1, X-4. [pmid: 11799656].
2219 McClannahan LE, McGee GG, MacDuff GS, et al. Assessing and improving child care: a personal appearance index for children with autism. J Appl Behav Anal. Winter. 1990;23(4):469-82. X-4, X-10. [pmid: 2074237].
2220 McClean B, Grey IM, McCracken M. An evaluation of positive behavioural support for people with very severe challenging behaviours in community-based settings. J Intellect Disabil. 09. 2007;11(3):281-301. X-1, X-3. [pmid: 17846050].
2221 McClure MK, Holtz-Yotz M. The effects of sensory stimulatory treatment on an autistic child. American Journal of Occupational Therapy. 12. 1991;45(12):1138-1142. X-1, X-3, X-10. [pmid: 1805627].
2222 McComas J, Hoch H, Paone D, et al. Escape behavior during academic tasks: A preliminary analysis of idiosyncratic establishing conditions. Journal of Applied Behavior Analysis. Special Issue: Establishing operations in applied behavior analysis. Win. 2000;33(4):479-493. X-3.
2223 McComas JJ, Thompson A, Johnson L. The effects of presession attention on problem behavior maintained by different reinforcers. J Appl Behav Anal. Fall. 2003;36(3):297-307. X-1, X-3, X-4. [pmid: 14596571].
2224 McConachie H, Barry R, Spencer A, et al. Dasl(n)e: the challenge of developing a regional database for autism spectrum disorder. Arch Dis Child. 01. 2009;94(1):38-41. X-4. [pmid: 18456689].
2225 McConachie H, Diggle T. Parent implemented early intervention for young children with autism spectrum disorder: a systematic review. J Eval Clin Pract. 02. 2007;13(1):120-9. X-2. [pmid: 17286734].
2226 McConachie H, Robinson G. What services do young children with autism spectrum disorder receive?. Child Care Health Dev. 09. 2006;32(5):553-7. X-1, X-3, X-4. [pmid: 16919134].
2227 McConnell SR. Interventions to facilitate social interaction for young children with autism: review of available research and recommendations for educational intervention and future research. J Autism Dev Disord. 10. 2002;32(5):351-72. X-1, X-2, X-3, X-4. [pmid: 12463515].
2228 McCormick MC. The autism “epidemic”: impressions from the perspective of immunization safety review. Ambul Pediatr. 05–06. 2003;3(3):119-20. X-1, X-2, X-3, X-4. [pmid: 12708887].
2229 McCrory E, Henry LA, Happe F. Eye-witness memory and suggestibility in children with Asperger syndrome. J Child Psychol Psychiatry. 05. 2007;48(5):482-9. X-4. [pmid: 17501729].
2230 McDaniel KD. Pharmacologic treatment of psychiatric and neurodevelopmental disorders in children and adolescents (Part 2). Clin Pediatr (Phila). 03. 1986;25(3):143-6. X-1, X-2, X-3, X-4, X-10. [pmid: 2868821].
2231 McDermott S, Moran R, Platt T, et al. Prevalence of Epilepsy in Adults With Mental Retardation and Related Disabilities in Primary Care. American Journal on Mental Retardation. 01. 2005;110(1):48-56. X-1, X-4. [pmid: 15568966].
2232 McDermott S, Zhou L, Mann J. Injury treatment among children with autism or pervasive developmental disorder. J Autism Dev Disord. 04. 2008;38(4):626-33. X-4. [pmid: 17690968].
2233 McDonald ME, Hemmes NS. Increases in Social Initiation toward an Adolescent with Autism: Reciprocity Effects. Research in Developmental Disabilities Journal Citation. 11–12. 2003;24(6):453-65. Publisher:. 2003 Pub Types: Journal Articles; Reports - Research. X-1, X-3, X-4.
2234 McDonnell A, Sturmey P, Oliver C, et al. The Effects of Staff Training on Staff Confidence and Challenging Behavior in Services for People with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 04–06. 2008;2(2):311-319. X-1, X-3, X-4.
2235 McDonnell J, Thorson N, McQuivey C, et al. Academic engaged time of students with low-incidence disabilities in general education classes. Ment Retard. 02. 1997;35(1):18-26. X-3, X-4, X-10. [pmid: 9046783].
2236 McDonnell MA, Hamrin V, Moffett J, et al. Timely diagnosis of comorbid pervasive developmental disorder and bipolar disorder. Minerva Pediatr. 02. 2008;60(1):115-27. X-1, X-2, X-4. [pmid: 18277370].
2237 McDougle CJ, Brodkin ES, Naylor ST, et al. Sertraline in adults with pervasive developmental disorders: a prospective open-label investigation. J Clin Psychopharmacol. 02. 1998;18(1):62-6. X-1, X-3, X-10. [pmid: 9472844].
2238 McDougle CJ, Brodkin ES, Yeung PP, et al. Risperidone in adults with autism or pervasive developmental disorder. Journal of Child and Adolescent Psychopharmacology. Win. 1995;5(4):273-282. X-1, X-3, X-10.
2239 McDougle CJ, Holmes JP, Bronson MR, et al. Risperidone treatment of children and adolescents with pervasive developmental disorders: a prospective open-label study. J Am Acad Child Adolesc Psychiatry. 05. 1997;36(5):685-93. X-10. [pmid: 9136504].
2240 McDougle CJ, Holmes JP, Carlson DC, et al. A double-blind, placebo-controlled study of risperidone in adults with autistic disorder and other pervasive developmental disorders. Arch Gen Psychiatry. 07. 1998;55(7):633-41. X-1, X-3, X-10. [pmid: 9672054].
2241 McDougle CJ, Kem DL, Posey DJ. Case series: use of ziprasidone for maladaptive symptoms in youths with autism. J Am Acad Child Adolesc Psychiatry. 08. 2002;41(8):921-7. X-1. [pmid: 12164181].
2242 McDougle CJ, Kresch LE, Goodman WK, et al. A case-controlled study of repetitive thoughts and behavior in adults with autistic disorder and obsessive-compulsive disorder. Am J Psychiatry. 05. 1995;152(5):772-7. X-1, X-4, X-10. [pmid: 7726318].
2243 McDougle CJ, Kresch LE, Posey DJ. Repetitive thoughts and behavior in pervasive developmental disorders: treatment with serotonin reuptake inhibitors. J Autism Dev Disord. 10. 2000;30(5):427-35. X-1, X-2, X-3. [pmid: 11098879].
2244 McDougle CJ, Naylor ST, Cohen DJ, et al. Effects of tryptophan depletion in drug-free adults with autistic disorder. Arch Gen Psychiatry. 11. 1996;53(11):993-1000. X-1, X-3, X-10. [pmid: 8911222].
2245 McDougle CJ, Naylor ST, Cohen DJ, et al. A double-blind, placebo-controlled study of fluvoxamine in adults with autistic disorder. Arch Gen Psychiatry. 11. 1996;53(11):1001-8. X-1, X-3, X-10. [pmid: 8911223].
2246 McDougle CJ, Posey D. Genetics of childhood disorders: XLIV. autism, part 3: psychopharmacology of autism. J Am Acad Child Adolesc Psychiatry. 11. 2002;41(11):1380-3. X-1, X-2, X-3, X-4. [pmid: 12410082].
2247 McDougle CJ, Price LH, Goodman WK. Fluvoxamine treatment of coincident autistic disorder and obsessive-compulsive disorder: A case report. Journal of Autism and Developmental Disorders. 12. 1990;20(4):537-543. X-1, X-3, X-10. [pmid: 2126264].
2248 McDougle CJ, Price LH, Volkmar FR, et al. Clomipramine in autism: Preliminary evidence of efficacy. Journal of the American Academy of Child & Adolescent Psychiatry. 07. 1992;31(4):746-750. X-1, X-3, X-10. [pmid: 1644740].
2249 McDougle CJ, Scahill L, McCracken JT, et al. Research Units on Pediatric Psychopharmacology (RUPP) Autism Network. and rationale for an initial controlled study of risperidone. Child Adolesc Psychiatr Clin N Am. 01. 2000;9(1):201-24. X-1, X-2, X-3, X-4. [pmid: 10674197].
2250 McDougle CJ, Stigler KA, Posey DJ. Treatment of aggression in children and adolescents with autism and conduct disorder. J Clin Psychiatry. 2003;64(Suppl 4):16-25. X-1, X-2, X-3. [pmid: 12672261].
2251 McDuffie A, Turner L, Stone W, et al. Developmental Correlates of Different Types of Motor Imitation in Young Children with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 03. 2007;37(3):401-412. X-4. [pmid: 16900404].
2252 McDuffie AS, Yoder PJ, Stone WL. Labels Increase Attention to Novel Objects in Children with Autism and Comprehension-Matched Children with Typical Development. Autism: The International Journal of Research & Practice. 2006;10(3):288-301. X-4. [pmid: 16682399].
2253 McEachin JJ, Smith T, Lovaas OI. Long-term outcome for children with autism who received early intensive behavioral treatment. Am J Ment Retard. 01. 1993;97(4):359-72. discussion 373–91. X-10. [pmid: 8427693].
2254 McEntee JE, Saunders RR. A response-restriction analysis of stereotypy in adolescents with mental retardation: implications for applied behavior analysis. J Appl Behav Anal. Fall. 1997;30(3):485-506. X-3, X-4, X-10. [pmid: 9316261].
2255 McEvoy MA, Brady MP. Contingent access to play materials as an academic motivator for autistic and behavior disordered children. Education & Treatment of Children. 02. 1988;11(1):5-18. X-3, X-10.
2256 McEvoy MA, Nordquist VM, Twardosz S, et al. Promoting autistic children’s peer interaction in an integrated early childhood setting using affection activities. J Appl Behav Anal. Summer. 1988;21(2):193-200. X-3, X-10. [pmid: 3417581].
2257 McGee GG, Almeida MC, Sulzer-Azaroff B, et al. Promoting reciprocal interactions via peer incidental teaching. J Appl Behav Anal. Spring. 1992;25(1):117-26. X-3, X-10. [pmid: 1582961].
2258 McGee GG, Feldman RS, Morrier MJ. Benchmarks of social treatment for children with autism. J Autism Dev Disord. 08. 1997;27(4):353-64. X-4, X-10. [pmid: 9261663].
2259 McGee GG, Krantz PJ, Mason D, et al. A modified incidental-teaching procedure for autistic youth: acquisition and generalization of receptive object labels. J Appl Behav Anal. Fall. 1983;16(3):329-38. X-3, X-10. [pmid: 6643324].
2260 McGee GG, Krantz PJ, McClannahan LE. Conversational skills for autistic adolescents: teaching assertiveness in naturalistic game settings. J Autism Dev Disord. 09. 1984;14(3):319-30. X-1, X-3, X-10. [pmid: 6480549].
2261 McGee GG, Krantz PJ, McClannahan LE. An extension of incidental teaching procedures to reading instruction for autistic children. J Appl Behav Anal. Summer. 1986;19(2):147-57. X-3, X-10. [pmid: 3733586].
2262 McGill P, Murphy G, Kelly-Pike A. Frequency of Use and Characteristics of People with Intellectual Disabilities Subject to Physical Interventions. Journal of Applied Research in Intellectual Disabilities. 03. 2009;22(2):152-158. X-1, X-4.
2263 McGreevy D. Risks and benefits of the single versus the triple MMR vaccine: how can health professionals reassure parents?. J R Soc Promot Health. 03. 2005;125(2):84-6. X-1, X-2, X-3, X-4. [pmid: 15819183].
2264 McGregor E, Campbell E. The attitudes of teachers in Scotland to the integration of children with autism into mainstream schools. Autism. 06. 2001;5(2):189-207. X-1, X-3, X-4. [pmid: 11706866].
2265 McGurk SR, Mueser KT, Feldman K, et al. Cognitive training for supported employment: 2–3 year outcomes of a randomized controlled trial. Am J Psychiatry. 03. 2007;164(3):437-41. X-1, X-4. [pmid: 17329468].
2266 McGurk SR, Mueser KT, Pascaris A. Cognitive training and supported employment for persons with severe mental illness: one-year results from a randomized controlled trial. Schizophr Bull. 10. 2005;31(4):898-909. X-1, X-4. [pmid: 16079391].
2267 McHale SM, Olley JG, Marcus LM, et al. Nonhandicapped peers as tutors for autistic children. Except Child. 11. 1981;48(3):263-5. X-10. [pmid: 7297587].
2268 McHale SM, Simeonsson RJ, Marcus LM, et al. The social and symbolic quality of autistic children’s communication. J Autism Dev Disord. 09. 1980;10(3):299-310. X-4, X-10. [pmid: 6085946].
2269 McIntyre LL, Blacher J, Baker BL. Behaviour/mental health problems in young adults with intellectual disability: the impact on families. J Intellect Disabil Res. 03. 2002;46(Pt 3):239-49. X-1, X-3, X-4. [pmid: 11896809].
2270 McKee SA, Harris GT, Rice ME, et al. Effects of a Snoezelen room on the behavior of three autistic clients. Res Dev Disabil. 05–06. 2007;28(3):304-16. X-3. [pmid: 16806812].
2271 McKeegan GF, Estill K, Campbell B. Elimination of rumination by controlled eating and differential reinforcement. Journal of Behavior Therapy and Experimental Psychiatry. 06. 1987;18(2):143-148. X-1, X-3, X-10. [pmid: 3611383].
2272 McKeegan GF, Estill K, Campbell BM. Brief report: Use of nonexclusionary timeout for the elimination of a stereotyped behavior. Journal of Behavior Therapy and Experimental Psychiatry. 09. 1984;15(3):261-264. X-1, X-3, X-10. [pmid: 6490938].
2273 McLellan A, Davies S, Heyman I, et al. Psychopathology in children with epilepsy before and after temporal lobe resection. Dev Med Child Neurol. 10. 2005;47(10):666-72. X-1, X-4. [pmid: 16174309].
2274 McLennan JD, Huculak S, Sheehan D. Brief report: pilot investigation of service receipt by young children with autistic spectrum disorders. J Autism Dev Disord. 07. 2008;38(6):1192-6. X-1, X-4. [pmid: 18324468].
2275 McLennan JD, Lord C, Schopler E. Sex differences in higher functioning people with autism. J Autism Dev Disord. 06. 1993;23(2):217-27. X-4, X-10. [pmid: 8331044].
2276 McMahon CR, Malesa EE, Yoder PJ, et al. Parents of Children with Autism Spectrum Disorders Have Merited Concerns about Their Later-Born Infants. Research and Practice for Persons with Severe Disabilities (RPSD). Sum. 2007;32(2):154-160. X-1, X-4.
2277 McNally RJ, Calamari JE, Hansen PM, et al. Behavioral treatment of psychogenic polydipsia. Journal of Behavior Therapy and Experimental Psychiatry. 03. 1988;19(1):57-61. X-1, X-3, X-10. [pmid: 3392224].
2278 McNeilly LG, Sheppard JJ. Prologue: Managing dysphagia in the schools. Lang Speech Hear Serv Sch. 04. 2008;39(2):158-9. X-1, X-2, X-3, X-4. [pmid: 18420518].
2279 McWilliam RA. What Happened to Service Coordination?. Journal of Early Intervention. 2006;28(3):166-168. X-1, X-2, X-3, X-4.
2280 Meadan H, Ostrosky MM, Zaghlawan HY, et al. Promoting the Social and Communicative Behavior of Young Children with Autism Spectrum Disorders: A Review of Parent-Implemented Intervention Studies. Topics in Early Childhood Special Education. 2009;29(2):90-104. X-1, X-2, X-3, X-4.
2281 Meador SK, Derby KM, McLaughlin TF, et al. Using Response Latency within a Preference Assessment. Behavior Analyst Today. 2007;8(1):63-69. X-1, X-3, X-4.
2282 Meany-Daboul MG, Roscoe EM, Bourret JC, et al. A Comparison of Momentary Time Sampling and Partial-Interval Recording for Evaluating Functional Relations. Journal of Applied Behavior Analysis. Fall. 2007;40(3):501-514. X-3. [pmid: 17970263].
2283 Mechling LC, Gast DL, Cronin BA. The Effects of Presenting High-Preference Items, Paired with Choice, via Computer-Based Video Programming on Task Completion of Students with Autism, Focus on Autism and Other Developmental Disabilities Journal Citation. Spr. 2006;21(1):7-13. Publisher: PRO-ED, Inc. 8700 Shoal Creek Boulevard, Austin, TX 78757-6897. Tel: 800-897-3202; Fax: 800-397-7633; Web site: http://www.proedinc.com. 2006 Pub Types: Journal Articles; Reports - Evaluative. X-1, X-3.
2284 Mechling LC, Pridgen LS, Cronin BA. Computer-Based Video Instruction to Teach Students with Intellectual Disabilities to Verbally Respond to Questions and Make Purchases in Fast Food Restaurants. Education and Training in Developmental Disabilities. 03. 2005;40(1):47-59. X-1, X-3, X-4.
2285 Megson MN. Is autism a G-alpha protein defect reversible with natural vitamin A?. Med Hypotheses. 06. 2000;54(6):979-83. X-4. [pmid: 10867750].
2286 Mehlinger R, Scheftner WA, Poznanski E. Fluoxetine and autism. Journal of the American Academy of Child & Adolescent Psychiatry. 11. 1990;29(6):985. X-1, X-3, X-10.
2287 Mehta UC, Patel I, Castello FV. EEG sedation for children with autism. J Dev Behav Pediatr. 04. 2004;25(2):102-4. X-1, X-3, X-4. [pmid: 15083132].
2288 Meigooni AS, Parker SA, Zheng J, et al. Dosimetric characteristics with spatial fractionation using electron grid therapy. Med Dosim. Spring. 2002;27(1):37-42. X-1, X-3, X-4. [pmid: 12019964].
2289 Meilleur AA, Fombonne E. Regression of language and non-language skills in pervasive developmental disorders. J Intellect Disabil Res. 02. 2009;53(2):115-24. X-4. [pmid: 19054269].
2290 Meiri G, Bichovsky Y, Belmaker RH. Omega 3 fatty acid treatment in autism. Journal of Child and Adolescent Psychopharmacology. 08. 2009;19(4):449-451. X-3. [pmid: 19702497].
2291 Meiselas KD, Spencer EK, Oberfield R, et al. Differentiation of stereotypies from neuroleptic-related dyskinesias in autistic children. J Clin Psychopharmacol. 06. 1989;9(3):207-9. X-1, X-3, X-4, X-10. [pmid: 2500463].
2292 Meissner HC, Strebel PM, Orenstein WA. Measles vaccines and the potential for worldwide eradication of measles. Pediatrics. 10. 2004;114(4):1065-9. X-1, X-2, X-3, X-4. [pmid: 15466106].
2293 Menear KS, Smith S. Physical Education for Students with Autism: Teaching Tips and Strategies. TEACHING Exceptional Children. 05–06. 2008;40(5):32-37. X-1, X-2, X-3, X-4.
2294 Menezes CG, Perissinoto J. Joint attention ability in children with autistic spectrum disorders. Pro Fono. 10–12. 2008;20(4):273-9. X-4. [pmid: 19142472].
2295 Menyuk P. Language development in a social context. J Pediatr. 07. 1986;109(1):217-24. X-10. [pmid: 2425068].
2296 Merlo LJ, Lehmkuhl HD, Geffken GR, et al. Decreased Family Accommodation Associated with Improved Therapy Outcome in Pediatric Obsessive-Compulsive Disorder. Journal of Consulting and Clinical Psychology. 04. 2009;77(2):355-360. X-1, X-3, X-4. [pmid: 19309195].
2297 Mesibov GB. Social skills training with verbal autistic adolescents and adults: a program model. J Autism Dev Disord. 12. 1984;14(4):395-404. X-1, X-3, X-10. [pmid: 6520094].
2298 Mesibov GB. Normalization and its relevance today. J Autism Dev Disord. 09. 1990;20(3):379-90. X-1, X-2, X-3, X-4, X-10. [pmid: 1699925].
2299 Mesibov GB. Commentary: facilitated communication: a warning for pediatric psychologists. J Pediatr Psychol. 02. 1995;20(1):127-30. X-1, X-2, X-3, X-4, X-10. [pmid: 7891235].
2300 Mesibov GB. Preschool issues in autism: introduction. J Autism Dev Disord. 12. 1997;27(6):637-40. X-10. [pmid: 9455725].
2301 Mesibov GB. Are children with autism better off in an autism classroom or a multidisability classroom?. J Autism Dev Disord. 10. 1999;29(5):429. X-10. [pmid: 10587891].
2302 Mesibov GB, Schopler E, Caison W. The Adolescent and Adult Psychoeducational Profile: assessment of adolescents and adults with severe developmental handicaps. J Autism Dev Disord. 03. 1989;19(1):33-40. X-1, X-3, X-4, X-10. [pmid: 2708302].
2303 Messieha Z, Cruz-Gonzalez W, Hakim MI. Retrospective outcomes evaluation of 100 parenteral moderate and deep sedations conducted in a general practice dental residency. Anesth Prog. Winter. 2008;55(4):116-20. X-4. [pmid: 19108595].
2304 Messmer RL, Nader R, Craig KD. Brief report: judging pain intensity in children with autism undergoing venepuncture: the influence of facial activity. J Autism Dev Disord. 08. 2008;38(7):1391-4. X-4. [pmid: 18161016].
2305 Meydanci TP, Kemikler G. Effect of a carbon fiber tabletop on the surface dose and attenuation for high-energy photon beams. Radiat Med. 11. 2008;26(9):539-44. X-1, X-4. [pmid: 19030962].
2306 Meyer JA, Hobson RP. Orientation in relation to self and other: The case of autism. Interaction Studies: Social Behaviour and Communication in Biological and Artificial Systems. 2004;5(2):221-244. X-4.
2307 Meyer LH, Fox A, Schermer A, et al. The effects of teacher intrusion on social play interactions between children with autism and their nonhandicapped peers. Journal of Autism and Developmental Disorders. 09. 1987;17(3):315-332. X-10. [pmid: 3654485].
2308 Miano S, Bruni O, Elia M, et al. Sleep in children with autistic spectrum disorder: a questionnaire and polysomnographic study. Sleep Med. 12. 2007;9(1):64-70. X-4. [pmid: 17728182].
2309 Michaud F, Salter T, Duquette A, et al. Perspectives on mobile robots as tools for child development and pediatric rehabilitation. Assist Technol. Spring. 2007;19(1):21-36. X-1, X-2, X-4. [pmid: 17461288].
2310 Micheli E. A training group for parents of autistic children. International Journal of Mental Health. Fal. 1999;28(3):100-105. X-1, X-4, X-10.
2311 Michelson D, Allen AJ, Busner J, et al. Once-daily atomoxetine treatment for children and adolescents with attention deficit hyperactivity disorder: a randomized, placebo-controlled study. Am J Psychiatry. 11. 2002;159(11):1896-901. X-1, X-4. [pmid: 12411225].
2312 Mickel J, Griffin J. Inclusion and Disability Awareness Training for Educators in the Kids Like You, Kids Like Me Program. Young Children. 07. 2007;62(4):42-45. X-1, X-2, X-3, X-4.
2313 Miilher LP, Fernandes FD. Pragmatic, lexical and grammatical abilities of autistic spectrum children. Pro Fono. 10–12. 2009;21(4):309-14. X-4. [pmid: 20098949].
2314 Mikkelsen EJ. Efficacy of neuroleptic medication in pervasive developmental disorders of childhood. Schizophr Bull. 1982;8(2):320-32. X-1, X-2, X-3, X-10. [pmid: 6126001].
2315 Mildon RL, Moore DW, Dixon RS. Combining Noncontingent Escape and Functional Communication Training as a Treatment for Negatively Reinforced Disruptive Behavior. Journal of Positive Behavior Interventions Journal Citation. 2004;6(2):92-102. Publisher: SAGE Publications. 2455 Teller Road, Thousand Oaks, CA 91320. Tel: 800-818-7243; Tel: 805-499-9774; Fax: 800-583-2665; e-mail: journals@sagepub.com; Web site: http://sagepub.com. 2004 Pub Types: Journal Articles; Reports - Research. X-3.
2316 Millar DC, Light JC, Schlosser RW. The Impact of Augmentative and Alternative Communication Intervention on the Speech Production of Individuals with Developmental Disabilities: A Research Review. Journal of Speech, Language, and Hearing Research. 04. 2006;49(2):248-264. X-1, X-2, X-3.
2317 Miller AR, Zwaigenbaum L. New provincial initiatives for childhood disabilities: the imperative for research. CMAJ. 06. 12. 2001;164(12):1704-5. X-1, X-2, X-3, X-4. [pmid: 11450214].
2318 Miller B. “A Kaleidoscope of Themes”: Intensive Psychotherapy with a Girl on the Autistic Spectrum. Journal of Child Psychotherapy. 12. 2008;34(3):384-399. X-3.
2319 Miller C, Collins BC, Hemmeter ML. Using a naturalistic time delay procedure to teach nonverbal adolescents with moderate-to-severe mental disabilities to initiate manual signs. Journal of Developmental and Physical Disabilities. 09. 2002;14(3):247-261. X-1, X-3.
2320 Miller E, Andrews N, Grant A, et al. No evidence of an association between MMR vaccine and gait disturbance. Arch Dis Child. 03. 2005;90(3):292-6. X-1, X-4. [pmid: 15723921].
2321 Miller JM, Singer HS, Bridges DD, et al. Behavioral therapy for treatment of stereotypic movements in nonautistic children. J Child Neurol. 02. 2006;21(2):119-25. X-1, X-4. [pmid: 16566875].
2322 Millward C, Ferriter M, Calver S, et al. Gluten- and casein-free diets for autistic spectrum disorder. Cochrane Database Syst Rev. 2004;(2):CD003498. X-2.
2323 Millward C, Ferriter M, Calver S, et al. Gluten- and casein-free diets for autistic spectrum disorder. Cochrane Database Syst Rev. 2008;(2):CD003498. X-2.
2324 Minagawa-Kawai Y, Naoi N, Kikuchi N, et al. Cerebral laterality for phonemic and prosodic cue decoding in children with autism. Neuroreport. 08. 26. 2009;20(13):1219-24. X-4. [pmid: 19617855].
2325 Minderaa RB, Anderson GM, Volkmar FR, et al. Neurochemical study of dopamine functioning in autistic and normal subjects. J Am Acad Child Adolesc Psychiatry. 03. 1989;28(2):190-4. X-4, X-10. [pmid: 2925571].
2326 Minderaa RB, Anderson GM, Volkmar FR, et al. Noradrenergic and adrenergic functioning in autism. Biol Psychiatry. 08. 15. 1994;36(4):237-41. X-4, X-10. [pmid: 7986888].
2327 Minderaa RB, Anderson GM, Volkmar FR, et al. Whole blood serotonin and tryptophan in autism: temporal stability and the effects of medication. J Autism Dev Disord. 03. 1989;19(1):129-36. X-4, X-10. [pmid: 2708296].
2328 Minett TS, Thomas A, Wilkinson LM, et al. What happens when donepezil is suddenly withdrawn? An open label trial in dementia with Lewy bodies and Parkinson’s disease with dementia. Int J Geriatr Psychiatry. 11. 2003;18(11):988-93. X-1, X-3, X-4. [pmid: 14618549].
2329 Ming X, Gordon E, Kang N, et al. Use of clonidine in children with autism spectrum disorders. Brain Dev. 08. 2008;30(7):454-60. X-3. [pmid: 18280681].
2330 Minio-Paluello I, Baron-Cohen S, Avenanti A, et al. Absence of embodied empathy during pain observation in Asperger syndrome. Biol Psychiatry. 01. 1. 2009;65(1):55-62. X-1, X-4. [pmid: 18814863].
2331 Miniscalco C, Hagberg B, Kadesjo B, et al. Narrative Skills, Cognitive Profiles and Neuropsychiatric Disorders in 7–8-Year-Old Children with Late Developing Language. International Journal of Language & Communication Disorders. 11. 2007;42(6):665-681. X-4. [pmid: 17852517].
2332 Minnes P, Steiner K. Parent views on enhancing the quality of health care for their children with fragile X syndrome, autism or Down syndrome. Child Care Health Dev. 03. 2009;35(2):250-6. X-1, X-4. [pmid: 19228158].
2333 Minshew NJ, Goldstein G, Taylor HG, et al. Academic achievement in high functioning autistic individuals. J Clin Exp Neuropsychol. 04. 1994;16(2):261-70. X-4, X-10. [pmid: 8021313].
2334 Miral S, Gencer O, Inal-Emiroglu FN, et al. Risperidone versus haloperidol in children and adolescents with AD : a randomized, controlled, double-blind trial. Eur Child Adolesc Psychiatry. 02. 2008;17(1):1-8. X-3. [pmid: 18080171].
2335 Miranda-Linne F, Melin L. Acquisition, generalization, and spontaneous use of color adjectives: a comparison of incidental teaching and traditional discrete-trial procedures for children with autism. Res Dev Disabil. 1992;13(3):191-210. X-3, X-10. [pmid: 1626079].
2336 Mirenda P, Locke PA. A comparison of symbol transparency in nonspeaking persons with intellectual disabilities. J Speech Hear Disord. 05. 1989;54(2):131-40. X-4, X-10. [pmid: 2709831].
2337 Mirenda PL, Donnellan AM, Yoder DE. Gaze behavior: a new look at an old problem. J Autism Dev Disord. 12. 1983;13(4):397-409. X-1, X-2, X-4, X-10. [pmid: 6662843].
2338 Mishna F, Muskat B. Group therapy for boys with features of Asperger syndrome and concurrent learning disabilities: Finding a peer group. Journal of Child & Adolescent Group Therapy. 09. 1998;8(3):97-114. X-3, X-10.
2339 Mitchell P, Parsons S, Leonard A. Using virtual environments for teaching social understanding to 6 adolescents with autistic spectrum disorders. J Autism Dev Disord. 03. 2007;37(3):589-600. X-1, X-3. [pmid: 16900403].
2340 Mithaug DK, Mithaug DE. Effects of teacher-directed versus student-directed instruction on self-management of young children with disabilities. J Appl Behav Anal. Spring. 2003;36(1):133-6. X-3. [pmid: 12723878].
2341 MJ CMM, de Gelder B, van Engeland H, et al. Atypical processing of fearful face-voice pairs in Pervasive Developmental Disorder: an ERP study. Clin Neurophysiol. 09. 2008;119(9):2004-10. X-1, X-4. [pmid: 18571467].
2342 MK DE. Infantile autism: patients and their families. Curr Probl Pediatr. 02. 1982;12(4):1-52. X-10.
2343 Moes DR. Integrating choice-making opportunities within teacher-assigned academic tasks to facilitate the performance of children with autism. Journal of the Association for Persons with Severe Handicaps. Win. 1998;23(4):319-328. X-10.
2344 Moes DR, Frea WD. Using family context to inform intervention planning for the treatment of a child with autism. Journal of Positive Behavior Interventions. Win. 2000;2(1):40-46. X-3.
2345 Moes DR, Frea WD. Contextualized behavioral support in early intervention for children with autism and their families. J Autism Dev Disord. 12. 2002;32(6):519-33. X-3. [pmid: 12553589].
2346 Mohan D, Taylor R, Mackeith JA. Cyproterone acetate and striae. International Journal of Psychiatry in Clinical Practice. 06. 1998;2(2):147-148. X-1, X-3, X-4, X-10.
2347 Mohr C, Sharpley CF. Elimination of self-injurious behaviour in an autistic child by use of overcorrection. Behaviour Change. 1985;2(2):143-147. X-3, X-10.
2348 Moller AR, Kern JK, Grannemann B. Are the non-classical auditory pathways involved in autism and PDD?. Neurol Res. 09. 2005;27(6):625-9. X-1, X-4. [pmid: 16157013].
2349 Molloy S, McKeith IG, O’Brien JT, et al. The role of levodopa in the management of dementia with Lewy bodies. J Neurol Neurosurg Psychiatry. 09. 2005;76(9):1200-3. X-1, X-4. [pmid: 16107351].
2350 Molloy SA, Rowan EN, O’Brien JT, et al. Effect of levodopa on cognitive function in Parkinson’s disease with and without dementia and dementia with Lewy bodies. J Neurol Neurosurg Psychiatry. 12. 2006;77(12):1323-8. X-1, X-4. [pmid: 16952917].
2351 Monji A, Maekawa T, Yanagimoto K, et al. Carbamazepine may trigger new-onset epileptic seizures in an individual with autism spectrum disorders: A case report. European Psychiatry. 08. 2004;19(5):322-323. X-3. [pmid: 15276670].
2352 Monsen RB. Watching children. J Pediatr Nurs. 12. 2008;23(6):469-70. X-1, X-2, X-3, X-4. [pmid: 19026915].
2353 Montee BB, Miltenberger RG, Wittrock D. An experimental analysis of facilitated communication. Journal of Applied Behavior Analysis. Sum. 1995;28(2):189-200. X-10. [pmid: 7601804].
2354 Montgomery JM, Duncan CR, Francis GC. Test Review: Siegel, B. (2004). “Pervasive Developmental Disorder Screening Test--II (PDDST-II).” San Antonio, TX: Harcourt. Journal of Psychoeducational Assessment. 2007;25(3):299-306. X-1, X-2, X-3, X-4.
2355 Montgomery JM, Newton B, Smith C, Gilliam J. “GARS-2: Gilliam Autism Rating Scale-Second Edition.” Austin, TX: PRO-ED. Journal of Psychoeducational Assessment. 2008. 2006;26(4):395-401. X-1, X-2, X-3, X-4.
2356 Montgomery JM, Schwean VL, Burt J-AG, et al. Emotional Intelligence and Resiliency in Young Adults with Asperger’s Disorder: Challenges and Opportunities. Canadian Journal of School Psychology. 2008;23(1):70-93. X-1, X-3, X-4.
2357 Moore BA, Friman PC, Fruzzetti AE, et al. Brief report: evaluating the Bedtime Pass Program for child resistance to bedtime--a randomized, controlled trial. J Pediatr Psychol. 04. 2007;32(3):283-7. X-1, X-4 9. [pmid: 16899650].
2358 Moore JW, Fisher WW, Pennington A. Systematic application and removal of protective equipment in the assessment of multiple topographies of self-injury. Journal of Applied Behavior Analysis. Spr. 2004;37(1):73-77. X-3, X-4. [pmid: 15154217].
2359 Moore ML, Eichner SF, Jones JR. Treating functional impairment of autism with selective serotonin-reuptake inhibitors. Ann Pharmacother. 09. 2004;38(9):1515-9. X-1, X-2, X-3, X-4. [pmid: 15292500].
2360 Moore SJ, Turnpenny P, Quinn A, et al. A clinical study of 57 children with fetal anticonvulsant syndromes. J Med Genet. 07. 2000;37(7):489-97. X-4. [pmid: 10882750].
2361 Moore V, Titcomb J, Cronk E, et al. Developing an autism assessment service I: Procedures, priorities, and pitfalls over the first 5 years. Child Psychology & Psychiatry Review. 1998;3(3):116-120. X-1, X-2, X-3, X-4, X-10.
2362 Moore V, Titcomb J, Johnson C, et al. Developing an autism assessment service II: Analysis of the first 81 cases seen. Child Psychology & Psychiatry Review. 1998;3(3):121-127. X-4, X-10.
2363 Moores DF. Issues in the modification of American sign language for instructional purposes. J Autism Dev Disord. 03. 1981;11(1):153-62. X-1, X-2, X-3, X-4, X-10. [pmid: 6927696].
2364 Morales AW. MEG reveals epileptic foci in brains of autistic children. Diagn Imaging (San Franc). 01. 1999;(Suppl):IR34. X-10, X-4.
2365 Moran DR, Whitman TL. Developing generalized teaching skills in mothers of autistic children. Child & Family Behavior Therapy. 1991;13(1):13-37. X-1, X-3, X-4, X-10.
2366 More C. Digital Stories Targeting Social Skills for Children with Disabilities: Multidimensional Learning. Intervention in School and Clinic. 2008;43(3):168-177. X-1, X-2, X-3, X-4.
2367 Moreland R. National vaccine injury compensation program: the potential impact of Cedillo for vaccine-related autism cases. J Leg Med. 07–09. 2008;29(3):363-80. X-1, X-2, X-3, X-4. [pmid: 18726760].
2368 Moreton J. MMR vaccination: protecting our children. J Fam Health Care. 2002;12(2):31. X-1, X-2, X-3, X-4. [pmid: 12415749].
2369 Moreton J. Who’s irresponsible?. Community Pract. 05. 2009;82(5):14. X-1, X-2, X-3, X-4.
2370 Moretti P, Sahoo T, Hyland K, et al. Cerebral folate deficiency with developmental delay, autism, and response to folinic acid. Neurology. 03. 2005;64(6):1088-1090. X-3. [pmid: 15781839].
2371 Moretti R, Torre P, Vilotti C, et al. Rivastigmine and Parkinson dementia complex. Expert Opin Pharmacother. 04. 2007;8(6):817-29. X-1, X-2, X-3, X-4. [pmid: 17425477].
2372 Morgan CN, Roy M, Chance P. Psychiatric comorbidity and medication use in autism: A community survey. Psychiatric Bulletin. 10. 2003;27(10):378-381. X-1, X-4.
2373 Morgan SB. Helping parents understand the diagnosis of autism. J Dev Behav Pediatr. 04. 1984;5(2):78-85. X-1, X-2, X-3, X-4, X-10. [pmid: 6715557].
2374 Morgan SB, Cutrer PS, Coplin JW, et al. Do autistic children differ from retarded and normal children in Piagetian sensorimotor functioning?. Journal of Child Psychology and Psychiatry. 11. 1989;30(6):857-864. X-10. [pmid: 2592469].
2375 Mori K, Ujiie T, Smith A, et al. Parental stress associated with caring for children with Asperger’s syndrome or autism. Pediatr Int. 06. 2009;51(3):364-70. X-1, X-4. [pmid: 19419495].
2376 Mori S. The role of the selfâ€”object experience in the therapy of an autistic child: From lying flat to launching a ‘spaceship.’. Journal of Child Psychotherapy. 08. 2001;27(2):159-173. X-3.
2377 Morinushi T, Ueda Y, Tanaka C. Autistic children: experience and severity of dental caries between 1980 and 1995 in Kagoshima City, Japan. J Clin Pediatr Dent. Summer. 2001;25(4):323-8. X-4. [pmid: 11497015].
2378 Morishita Y, Ando Y, Ishii E, et al. Comparison of markers of circulating blood volume in hemodialysis patients. Clin Exp Nephrol. 09. 2005;9(3):233-7. X-1, X-4. [pmid: 16189632].
2379 Morowitz HJ. Autism and authority. Hosp Pract (Off Ed). 04. 15. 1989;24(4):221-2. X-1, X-2, X-3, X-4, X-10.
2380 Morrier MJ, Hess KL, Heflin LJ. Ethnic Disproportionality in Students with Autism Spectrum Disorders. Multicultural Education. Fall. 2008;16(1):31-38. X-1, X-2, X-3, X-4.
2381 Morris CR, Agin MC. Syndrome of allergy, apraxia, and malabsorption: characterization of a neurodevelopmental phenotype that responds to omega 3 and vitamin E supplementation. Altern Ther Health Med. 07–08. 2009;15(4):34-43. X-4. [pmid: 19623831].
2382 Morris RG, Rowe A, Fox N, et al. Spatial working memory in Asperger’s syndrome and in patients with focal frontal and temporal lobe lesions. Brain Cogn. 10. 1999;41(1):9-26. X-4, X-10. [pmid: 10536083].
2383 Morrison EE. A Review of Research on the Use of Weighted Vests with Children on the Autism Spectrum. Education. Spr. 2007;127(3):323-327. X-1, X-2, X-3.
2384 Morrison L, Kamps D, Garcia J, et al. Peer mediation and monitoring strategies to improve initiations and social skills for students with autism. Journal of Positive Behavior Interventions. Fal. 2001;3(4):237-250. X-3.
2385 Morrison RS, Sainato DM, Benchaaban D, et al. Increasing play skills of children with autism using activity schedules and correspondence training. Journal of Early Intervention. Win-Spr. 2002;25(1):58-72. X-3.
2386 Morse TE, Schuster JW. Teaching Elementary Students with Moderate Intellectual Disabilities How To Shop for Groceries. Exceptional Children. 2000. X-1, X-3, X-4.
2387 Morton JF, Campbell JM. Information source affects peers’ initial attitudes toward autism. Res Dev Disabil. 05–06. 2008;29(3):189-201. X-1, X-4. [pmid: 17391914].
2388 Mosimann UP, Mather G, Wesnes KA, et al. Visual perception in Parkinson disease dementia and dementia with Lewy bodies. Neurology. 12. 14. 2004;63(11):2091-6. X-1, X-3, X-4. [pmid: 15596755].
2389 Moss HA, Brouwers P, Wolters PL, et al. The development of a Q-sort behavioral rating procedure for pediatric HIV patients. J Pediatr Psychol. 02. 1994;19(1):27-46. X-1, X-4, X-10. [pmid: 8151493].
2390 Moss J, Howlin P. Autism Spectrum Disorders in Genetic Syndromes: Implications for Diagnosis, Intervention and Understanding the Wider Autism Spectrum Disorder Population. Journal of Intellectual Disability Research. 10. 2009;53(10):852-873. X-1, X-2, X-3, X-4. [pmid: 19708861].
2391 Moss J, Magiati I, Charman T, et al. Stability of the autism diagnostic interview-revised from pre-school to elementary school age in children with autism spectrum disorders. J Autism Dev Disord. 07. 2008;38(6):1081-91. X-4. [pmid: 18058215].
2392 Mostafa GA, El-Sherif DF, Hamza RT, et al. Hyperserotonemia in Egyptian autistic children: Relation to allergic manifestations. Journal of Pediatric Neurology. 2008;6(3):227-236. X-4.
2393 Mostert MP. Facilitated communication since 1995: a review of published studies. J Autism Dev Disord. 06. 2001;31(3):287-313. X-1, X-2, X-3, X-4. [pmid: 11518483].
2394 Mouridsen SE, Rich B, Isager T. Validity of childhood disintegrative psychosis. General findings of a long-term follow-up study. Br J Psychiatry. 03. 1998;172:263-7. X-4, X-10. [pmid: 9614477].
2395 Mouridsen SE, Rich B, Isager T. Epilepsy in disintegrative psychosis and infantile autism: a long-term validation study. Dev Med Child Neurol. 02. 1999;41(2):110-4. X-4, X-10. [pmid: 10075096].
2396 Mouridsen SE, Rich B, Isager T. Psychiatric morbidity in disintegrative psychosis and infantile autism: A long-term follow-up study. Psychopathology. 07–08. 1999;32(4):177-83. X-4, X-10. [pmid: 10364726].
2397 Mouridsen SE, Rich B, Isager T, et al. Psychiatric disorders in the parents of individuals with infantile autism: a case-control study. Psychopathology. 2007;40(3):166-71. X-1, X-4. [pmid: 17318009].
2398 Moynahan L. Enhanced Aggression Replacement Training with Children and Youth with Autism Spectrum Disorder. Reclaiming Children and Youth: The Journal of Strength-based Interventions. Fall. 2003;12(3):174-180. X-1, X-2, X-3, X-4.
2399 Mraz KD, Dixon J, Dumont-Mathieu T, et al. Accelerated head and body growth in infants later diagnosed with autism spectrum disorders: A comparative study of optimal outcome children. Journal of Child Neurology. 2009;24(7):21. X-4.
2400 Mruzek DW, Cohen C, Smith T. Contingency contracting with students with autism spectrum disorders in a public school setting. Journal of Developmental and Physical Disabilities. 04. 2007;19(2):103-114. X-3.
2401 Msall ME, Avery RC, Tremont MR, et al. Functional disability and school activity limitations in 41,300 school-age children: relationship to medical impairments. Pediatrics. 03. 2003;111(3):548-53. X-4. [pmid: 12612235].
2402 Msall ME, Phelps DL, Hardy RJ, et al. Educational and social competencies at 8 years in children with threshold retinopathy of prematurity in the CRYO-ROP multicenter study. Pediatrics. 04. 2004;113(4):790-9. X-4. [pmid: 15060229].
2403 Muckian J. Influencing policy development: the whirling dervish of the autism in-home program. J Pediatr Nurs. 06. 2007;22(3):223-30. X-1, X-2, X-3, X-4. [pmid: 17524966].
2404 Mudford OC, Martin NT, Eikeseth S, et al. Parent-managed behavioral treatment for preschool children with autism: some characteristics of UK programs. Res Dev Disabil. 05–06. 2001;22(3):173-82. X-4. [pmid: 11380057].
2405 Mukaddes NM, Abali O, Gurkan K. Short-term efficacy and safety of risperidone in young children with autistic disorder (AD). World J Biol Psychiatry. 10. 2004;5(4):211-4. X-3. [pmid: 15543515].
2406 Mukaddes NM, Bilge S, Alyanak B, et al. Clinical characteristics and treatment responses in cases diagnosed as reactive attachment disorder. Child Psychiatry Hum Dev. Summer. 2000;30(4):273-87. X-1, X-3, X-4. [pmid: 10921209].
2407 Mulder H, Herder A, Wilmink FW, et al. The impact of cytochrome P450-2D6 genotype on the use and interpretation of therapeutic drug monitoring in long-stay patients treated with antidepressant and antipsychotic drugs in daily psychiatric practice. Pharmacoepidemiol Drug Saf. 02. 2006;15(2):107-14. X-1, X-4. [pmid: 16294366].
2408 Muller A, Monnet DL, Talon D, et al. Discrepancies between prescribed daily doses and WHO defined daily doses of antibacterials at a university hospital. Br J Clin Pharmacol. 05. 2006;61(5):585-91. X-1, X-4. [pmid: 16669851].
2409 Muller E, Schuler A, Yates GB. Social challenges and supports from the perspective of individuals with Asperger syndrome and other autism spectrum disabilities. Autism. 03. 2008;12(2):173-90. X-1, X-4. [pmid: 18308766].
2410 Mullins JL, Christian L. The effects of progressive relaxation training on the disruptive behavior of a boy with autism. Research in Developmental Disabilities. 11–12. 2001;22(6):449-462. X-3. [pmid: 11768670].
2411 Mullins M, Rincover A. Comparing autistic and normal children along the dimensions of reinforcement maximization, stimulus sampling, and responsiveness to extinction. Journal of Experimental Child Psychology. 10. 1985;40(2):350-374. X-3, X-10. [pmid: 4045384].
2412 Mundkur N. Developmental and behavioral pediatrics--the present and the future. Indian J Pediatr. 10. 2005;72(10):853. X-1, X-2, X-3, X-4. [pmid: 16272657].
2413 Munesue T, Ono Y, Mutoh K, et al. High prevalence of bipolar disorder comorbidity in adolescents and young adults with high-functioning autism spectrum disorder: a preliminary study of 44 outpatients. J Affect Disord. 12. 2008;111(2–3):170-5. X-1, X-4. [pmid: 18378000].
2414 Munson BL. Myths and facts...about autism. Nursing. 10. 2004;34(10):75. X-1, X-2, X-3, X-4.
2415 Murphy C, Barnes-Holmes D, Barnes-Holmes Y. Derived Manding in Children with Autism: Synthesizing Skinner’s Verbal Behavior with Relational Frame Theory. Journal of Applied Behavior Analysis. Win. 2005;38(4):445. X-3. [pmid: 16463526].
2416 Murphy DGM, Critchley HD, Schmitz N, et al. Asperger syndrome: A proton magnetic resonance spectroscopy study of brain. Archives of General Psychiatry. 10. 2002;59(10):885-892. X-1, X-3, X-4. [pmid: 12365875].
2417 Murphy G, Hall S, Oliver C, et al. Identification of early self-injurious behaviour in young children with intellectual disability. J Intellect Disabil Res. 06. 1999;43(Pt 3):149-63. X-4, X-10. [pmid: 10392602].
2418 Murphy G, Powell S, Guzman AM, et al. Cognitive-behavioural treatment for men with intellectual disabilities and sexually abusive behaviour: a pilot study. J Intellect Disabil Res. 11. 2007;51(Pt 11):902-12. X-1, X-4. [pmid: 17910542].
2419 Murphy JF. MMR and the measles crisis. Ir Med J. 03–04. 2000;93(2):36. X-1, X-2, X-3, X-4.
2420 Murphy JV, Wheless JW, Schmoll CM. Left vagal nerve stimulation in six patients with hypothalamic hamartomas. Pediatr Neurol. 08. 2000;23(2):167-8. X-3. [pmid: 11020644].
2421 Murphy O, Healy O, Leader G. Risk Factors for Challenging Behaviors among 157 Children with Autism Spectrum Disorder in Ireland. Research in Autism Spectrum Disorders. 04–06. 2009;3(2):474-482. X-4.
2422 Murray M, Baker PH, Murray-Slutsky C, et al. Strategies for Supporting the Sensory-Based Learner. Preventing School Failure. Sum. 2009;53(4):245-251. X-1, X-2, X-3, X-4.
2423 Murrell AR, Scherbarth AJ. State of the Research & Literature Address: ACT with Children, Adolescents and Parents. International Journal of Behavioral Consultation and Therapy. 2006;2(4):531-543. X-1, X-2, X-3, X-4.
2424 Murzynski NT, Bourret JC. Combining video modeling and least-to-most prompting for establishing response chains. Behavioral Interventions. 04. 2007;22(2):147-152. X-3.
2425 Music G. Surfacing the depths: Thoughts on imitation, resonance and growth. Journal of Child Psychotherapy. 04. 2005;31(1):72-90. X-3.
2426 Myers KM, Goulet M, Rusche J, et al. Partial reversal of phencyclidine-induced impairment of prepulse inhibition by secretin. Biol Psychiatry. 07. 1. 2005;58(1):67-73. X-1, X-2, X-3, X-4. [pmid: 15992525].
2427 Myers SM. The status of pharmacotherapy for autism spectrum disorders. Expert Opin Pharmacother. 08. 2007;8(11):1579-603. X-1, X-2, X-3. [pmid: 17685878].
2428 Myers SM. Management of autism spectrum disorders in primary care. Pediatr Ann. 01. 2009;38(1):42-9. X-1, X-2, X-3. [pmid: 19213293].
2429 Myers SM, Johnson CP. Management of children with autism spectrum disorders. Pediatrics. 11. 2007;120(5):1162-82. X-1, X-2, X-3, X-4. [pmid: 17967921].
2430 Myles BS. Behavioral forms of stress management for individuals with Asperger syndrome. Child Adolesc Psychiatr Clin N Am. 01. 2003;12(1):123-41. X-1, X-2, X-3, X-4. [pmid: 12512402].
2431 Myles BS, Ferguson H, Hagiwara T. Using a Personal Digital Assistant to Improve the Recording of Homework Assignments by an Adolescent with Asperger Syndrome. Focus on Autism and Other Developmental Disabilities. Sum. 2007;22(2):96-99. X-1, X-3.
2432 Myles BS, Grossman BG, Aspy R, et al. Planning a Comprehensive Program for Students with Autism Spectrum Disorders Using Evidence-Based Practices. Education and Training in Developmental Disabilities. 12. 2007;42(4):398-409. X-1, X-2, X-3, X-4.
2433 Myles BS, Simpson RL. Facilitated communication with children diagnosed as autistic in public school settings. Psychology in the Schools. 07. 1994;31(3):208-220. X-10.
2434 Myles BS, Simpson RL, Smith SM. Collateral behavioral and social effects of using facilitated communication with individuals with autism. Focus on Autism and Other Developmental Disabilities. Fal. 1996;11(3):163-169. 190. X-10.
2435 Myles BS, Simpson RL, Smith SM. Impact of facilitated communication combined with direct instruction on academic performance of individuals with autism. Focus on Autism and Other Developmental Disabilities. Spr. 1996;11(1):37-44. X-10.
2436 Nader R, Oberlander TF, Chambers CT, et al. Expression of pain in children with autism. Clin J Pain. 03–04. 2004;20(2):88-97. X-4. [pmid: 14770048].
2437 Naganuma GM, Billingsley FF. Effect of hand splints on stereotypic hand behavior of three girls with Rett syndrome. Phys Ther. 05. 1988;68(5):664-71. X-1, X-3, X-4, X-10. [pmid: 3362979].
2438 Nahshoni E, Spitzer S, Berant M, et al. QT interval and dispersion in very young children treated with antipsychotic drugs: a retrospective chart review. J Child Adolesc Psychopharmacol. 04. 2007;17(2):187-94. X-3, X-4. [pmid: 17489713].
2439 Najdowski AC, Wallace MD, Doney JK, et al. Parental assessment and treatment of food selectivity in natural settings. J Appl Behav Anal. Fall. 2003;36(3):383-6. X-3. [pmid: 14596582].
2440 Nalitz NG. Consultation and collaboration programs for individuals with autism. Clin Commun Disord. Winter. 1993;3(1):31-43. X-1, X-2, X-3, X-4, X-10.
2441 Namerow LB, Mangini LM. Targeting symptom domains: a strategy for pharmacotherapy in childhood pervasive developmental disorders. Conn Med. 10. 2005;69(9):525-33. X-1, X-2, X-3, X-4. [pmid: 16270789].
2442 Namerow LB, Thomas P, Bostic JQ, et al. Use of citalopram in pervasive developmental disorders. J Dev Behav Pediatr. 04. 2003;24(2):104-8. X-1. [pmid: 12692455].
2443 Naoi N, Tsuchiya R, Yamamoto J, et al. Functional training for initiating joint attention in children with autism. Res Dev Disabil. 11–12. 2008;29(6):595-609. X-3. [pmid: 18065199].
2444 Naoi N, Yokoyama K, Yamamoto J-i. Intervention for Tact as Reporting in Children with Autism. Research in Autism Spectrum Disorders. 04–06. 2007;1(2):174-184. X-3.
2445 Napolitano DA, Tessing JL, McAdam DB, et al. The Influence of Idiosyncratic Antecedent Variables on Problem Behavior Displayed by a Person with PDD. Journal of Developmental and Physical Disabilities. 09. 2006;18(3):295-305. X-3.
2446 Narayan J, Chakravarti SN, David J, et al. Analysis of educational support systems for children with mental retardation and autism spectrum disorders. Int J Rehabil Res. 12. 2005;28(4):365-8. X-4. [pmid: 16319564].
2447 Nataf R, Skorupka C, Amet L, et al. Porphyrinuria in childhood autistic disorder: implications for environmental toxicity. Toxicol Appl Pharmacol. 07. 15. 2006;214(2):99-108. X-4. [pmid: 16782144].
2448 Nation K, Norbury CF. Why Reading Comprehension Fails: Insights from Developmental Disorders. Topics in Language Disorders. 01–03. 2005;25(1):21. X-1, X-2, X-3, X-4.
2449 Neef NA. Pyramidal parent training by peers. J Appl Behav Anal. Fall. 1995;28(3):333-7. X-10. [pmid: 7592149].
2450 Neef NA, Shafer MS, Egel AL, et al. The class specific effects of compliance training with “do” and “don’t” requests: analogue analysis and classroom application. J Appl Behav Anal. Spring. 1983;16(1):81-99. X-10. [pmid: 6187723].
2451 Neef NA, Walters J, Egel AL. Establishing generative yes/no responses in developmentally disabled children. J Appl Behav Anal. Winter. 1984;17(4):453-60. X-3, X-10. [pmid: 6526766].
2452 Neidert PL, Iwata BA, Dozier CL. Treatment of Multiply Controlled Problem Behavior With Procedural Variations of Differential Reinforcement. Exceptionality. 2005;13(1):45-53. X-3.
2453 Nelson C, McDonnell AP, Johnston SS, et al. Keys to Play: A Strategy to Increase the Social Interactions of Young Children with Autism and their Typically Developing Peers. Education and Training in Developmental Disabilities. 06. 2007;42(2):165-181. X-3.
2454 Nelson D, Amplo K. Care of the autistic patient in the perioperative area. AORN J. 02. 2009;89(2):391-2. 395. 7. X-1, X-2, X-3, X-4. [pmid: 19200470].
2455 Nelson DL, Gergenti E, Hollander AC. Extra prompts versus no extra prompts in self-care training of autistic children and adolescents. J Autism Dev Disord. 09. 1980;10(3):311-21. X-10. [pmid: 6927657].
2456 Nelson EC, Pribor EF. A calendar savant with autism and Tourette syndrome: Response to treatment and thoughts on the interrelationships of these conditions. Annals of Clinical Psychiatry. 06. 1993;5(2):135-140. X-1, X-3, X-4, X-10. [pmid: 8348206].
2457 Nesbitt S. An evaluation of multi-agency service provision for children with autistic spectrum disorders. British Journal of Developmental Disabilities. 01. 2000;46(90, Pt 1):43-50. X-1, X-2, X-3, X-4.
2458 Nesbitt S. Why and why not? Factors influencing employment for individuals with Asperger syndrome. Autism. 12. 2000;4(4):357-369. X-1, X-4.
2459 Neufeld A, Fantuzzo JW. Contingent application of a protective device to treat the severe self-biting behavior of a disturbed autistic child. Journal of Behavior Therapy and Experimental Psychiatry. 03. 1984;15(1):79-83. X-3, X-10. [pmid: 6470161].
2460 Neufeld RE, Clark BG, Robertson CM, et al. Five-year neurocognitive and health outcomes after the neonatal arterial switch operation. J Thorac Cardiovasc Surg. 12. 2008;136(6):1413-21. 1421 e1. 1421 e2. X-4. [pmid: 19114183].
2461 Neuringer A. Reinforced Variability in Animals and People: Implications for Adaptive Action. American Psychologist. 12. 2004;59(9):891-906. X-1, X-2, X-3, X-4. [pmid: 15584823].
2462 Neves SN, Reimao R. Sleep disturbances in 50 children with attention-deficit hyperactivity disorder. Arq Neuropsiquiatr. 06. 2007;65(2A):228-33. X-1, X-4. [pmid: 17607419].
2463 Nevo Y, Shinnar S, Samuel E, et al. Unprovoked seizures and developmental disabilities: clinical characteristics of children referred to a child development center. Pediatr Neurol. 10. 1995;13(3):235-41. X-4, X-10. [pmid: 8554661].
2464 Newman B, Buffington DM, Hemmes NS. Self-reinforcement used to increase the appropriate conversation of autistic teenagers. Education & Training in Mental Retardation & Developmental Disabilities. 12. 1996;31(4):304-309. X-10.
2465 Newman B, Buffington DM, O’Grady MA, et al. Self-management of schedule following in three teenagers with autism. Behavioral Disorders. 05. 1995;20(3):190-196. X-1, X-3, X-10.
2466 Newman B, Needelman M, Reinecke DR, et al. The effect of providing choices on skill acquisition and competing behavior of children with autism during discrete trial instruction. Behavioral Interventions. 01–03. 2002;17(1):31-41. X-3.
2467 Newman B, Reinecke DR, Meinberg DL. Self-management of varied responding in three students with autism. Behavioral Interventions. 04–06. 2000;15(2):145-151. X-3.
2468 Newman B, Ten Eyck P. Self-management of initiations by students diagnosed with autism. Analysis of Verbal Behavior. 2005;21:117-122. X-3.
2469 Newman B, Tuntigian L, Ryan CS, et al. Self-management of a DRO procedure by three students with autism. Behavioral Interventions. 07. 1997;12(3):149-156. X-3, X-10.
2470 Neysmith-Roy JM. The Tomatis Method with severely autistic boys: Individual case studies of behavioural changes. South African Journal of Psychology. 03. 2001;31(1):19-28. X-3.
2471 Nicolson R, Awad G, Sloman L. An open trial of risperidone in young autistic children. J Am Acad Child Adolesc Psychiatry. 04. 1998;37(4):372-6. X-10. [pmid: 9549957].
2472 Nicolson R, Castellanos FX. Commentary: considerations on the pharmacotherapy of attention deficits and hyperactivity in children with autism and other pervasive developmental disorders. J Autism Dev Disord. 10. 2000;30(5):461-2. X-1, X-2, X-3, X-4. [pmid: 11098884].
2473 Nicolson R, Craven-Thuss B, Smith J. A prospective, open-label trial of galantamine in autistic disorder. J Child Adolesc Psychopharmacol. 10. 2006;16(5):621-9. X-3. [pmid: 17069550].
2474 Niederhofer H, Pittschieler K. A Preliminary Investigation of ADHD Symptoms in Persons with Celiac Disease. Journal of Attention Disorders. 2006;10(2):200-204. X-1, X-4. [pmid: 17085630].
2475 Niederhofer H, Staffen W, Mair A. Galantamine may be effective in treating autistic disorder. BMJ: British Medical Journal. 12. 2002;325(7377):1422-1423. X-3.
2476 Niederhofer H, Staffen W, Mair A. Tianeptine: a novel strategy of psychopharmacological treatment of children with autistic disorder. Hum Psychopharmacol. 07. 2003;18(5):389-93. X-3. [pmid: 12858327].
2477 Nikolopoulos TP, Archbold SM, Wever CC, et al. Speech production in deaf implanted children with additional disabilities and comparison with age-equivalent implanted children without such disorders. Int J Pediatr Otorhinolaryngol. 12. 2008;72(12):1823-8. X-3. [pmid: 18922585].
2478 Nikopoulos CK, Canavan C, Nikopoulou-Smyrni P. Generalized effects of video modeling on establishing instructional stimulus control in children with autism: Results of a preliminary study. Journal of Positive Behavior Interventions. 10. 2009;11(4):198-207. X-3.
2479 Nikopoulos CK, Keenan M. Promoting social initiation children with autism using video modeling. Behavioral Interventions. 04. 2003;18(2):87-108. X-3.
2480 Nikopoulos CK, Keenan M. Effects of Video Modeling on Social Initiations by Children with Autism. Journal of Applied Behavior Analysis. Spr. 2004;37(1):93. X-3. [pmid: 15154221].
2481 Nikopoulos CK, Nikopoulou-Smyrni P. Teaching Complex Social Skills to Children with Autism; Advances of Video Modeling. Journal of Early and Intensive Behavior Intervention. 2008;5(2):30-43. X-1, X-2, X-3.
2482 Nilsson M. Table Hockey: Attack or Linking? Psychoanalytic Psychotherapy with an Autistic Boy. Journal of Child Psychotherapy. 08. 2009;35(2):131-141. X-3.
2483 Nishioka M, Ishikawa M, Hanaki N, et al. Perioperative hemodynamic study of patients undergoing abdominal surgery using pulse dye densitometry. Hepatogastroenterology. 11–12. 2006;53(72):874-8. X-1, X-4. [pmid: 17153444].
2484 Nissen B. Hypochondria: a tentative approach. Int J Psychoanal. 08. 2000;81(Pt 4):651-66. X-1, X-3, X-4. [pmid: 11028232].
2485 Nizin P, Qian GX, Rashid H. “Zero-field” dose data for 60Co and other high-energy photon beams in water. Med Phys. 09–10. 1993;20(5):1353-60. X-1, X-2, X-3, X-4, X-10. [pmid: 8289716].
2486 Njardvik U, Matson JL, Cherry KE. A comparison of social skills in adults with autistic disorder, pervasive developmental disorder not otherwise specified, and mental retardation. J Autism Dev Disord. 08. 1999;29(4):287-95. X-1, X-3, X-4, X-10. [pmid: 10478728].
2487 Noell GH, Roane HS, Vanderhayden AM, et al. Programming for the Generalization of Communication to the Classroom Following Assessment and Training Outside of the Classroom. School Psychology Review Journal Citation. 2000;29(3):429-42. Publisher:. 2000 Pub Types: Information Analyses; Journal Articles; Reports - Research. X-3.
2488 Noens I, van Berckelaer-Onnes I. Making Sense in a Fragmentary World: Communication in People with Autism and Learning Disability. Autism The International Journal of Research and Practice. 06. 2004;8(2):197-218. X-1, X-2, X-3, X-4. [pmid: 15165435].
2489 Norbury CF, Bishop DV. Inferential processing and story recall in children with communication problems: a comparison of specific language impairment, pragmatic language impairment and high-functioning autism. Int J Lang Commun Disord. 07–09. 2002;37(3):227-51. X-4. [pmid: 12201976].
2490 Norman J. Freedom to play, dream and think. Scandinavian Psychoanalytic Review. 1999;22(2):172-188. X-3, X-4, X-10.
2491 Norman JM, Collins BC, Schuster JW. Using an Instructional Package Including Video Technology To Teach Self-Help Skills to Elementary Students with Mental Disabilities. Journal of Special Education Technology. 2001. X-3.
2492 Norris C, Dattilo J. Evaluating effects of a social story intervention on a young girl with autism. Focus on Autism and Other Developmental Disabilities. Fal. 1999;14(3):180-186. X-3, X-10.
2493 Novaes CM, PondÃƒÂ© MP, Freire ACC. Control of psychomotor agitation and aggressive behavior in patients with autistic disorder: A retrospective chart review. Arquivos de Neuro-Psiquiatria. 09. 2008;66(3-B):646-651. X-3. [pmid: 18949256].
2494 Novick B, Vaughan HG Jr, Kurtzberg D, et al. An electrophysiologic indication of auditory processing defects in autism. Psychiatry Res. 09. 1980;3(1):107-14. X-3, X-4, X-10. [pmid: 6934552].
2495 Nowakowski Z, Stelmachow J, Spiewankiewicz B, et al. Diagnostic value of the PDD method in evaluation of vulvar lesions. Eur J Gynaecol Oncol. 2005;26(1):75-8. X-1, X-4. [pmid: 15755006].
2496 Nowakowski Z, Stelmachow J, Spiewankiewicz B, et al. Diagnostic value of the photodynamic method in the evaluation of lesions of the uterine cervix. Eur J Gynaecol Oncol. 2005;26(3):315-22. X-1, X-4. [pmid: 15991536].
2497 Nuehring ML, Sitlington PL. Transition as a Vehicle: Moving From High School to an Adult Vocational Service Provider. Journal of Disability Policy Studies. Sum. 2003;14(1):23-35. X-1, X-3.
2498 Nunes D, Hanline MF. Enhancing the Alternative and Augmentative Communication Use of a Child with Autism through a Parent-Implemented Naturalistic Intervention. International Journal of Disability, Development and Education. 06. 2007;54(2):177-197. X-3.
2499 Nunes DRP. AAC Interventions for Autism: A Research Summary. International Journal of Special Education. 2008;23(2):17-26. X-2, X-3.
2500 Nuzzolo-Gomez R, Leonard MA, Ortiz E, et al. Teaching children with autism to prefer books or toys over stereotypy or passivity. Journal of Positive Behavior Interventions. Spr. 2002;4(2):80-87. X-3.
2501 Nwora AJ, Gee BM. A case study of a five-year-old child with pervasive developmental disorder-not otherwise specified using sound-based interventions. Occupational Therapy International. Special Issue: Occupational therapy and complementary and alternative medicine. 2009;16(1):25-43. X-3.
2502 Nyden A, Myren KJ, Gillberg C. Long-term psychosocial and health economy consequences of ADHD, autism, and reading-writing disorder: a prospective service evaluation project. J Atten Disord. 09. 2008;12(2):141-8. X-1. [pmid: 17968030].
2503 Nye C, Brice A. Combined vitamin B6-magnesium treatment in autism spectrum disorder. Cochrane Database Syst Rev. 2002;(4):CD003497. X-2.
2504 Nye C, Brice A. Combined vitamin B6-magnesium treatment in autism spectrum disorder. Cochrane Database Syst Rev. 2005;(4):CD003497. X-1, X-2, X-3, X-4.
2505 Nystul MS. Reaching in-reaching out: Counseling an autistic child. American Mental Health Counselors Association Journal. 01. 1986;8(1):18-26. X-3, X-10.
2506 Oades RD, Stern LM, Walker MK, et al. Event-related potentials and monoamines in autistic children on a clinical trial of fenfluramine. Int J Psychophysiol. 04. 1990;8(3):197-212. X-3, X-10. [pmid: 2187009].
2507 Oberleitner R. Talking to the autism community [interviewed by Semahat S Demir]. IEEE Eng Med Biol Mag. 01–02. 2005;24(1):14-5. 19. X-2.
2508 Oberleitner R, Laxminarayan S. Information technology and behavioral medicine: impact on autism treatment & research. Stud Health Technol Inform. 2004;103:215-22. X-1, X-2, X-3. [pmid: 15747924].
2509 O’Connor IM, Klein PD. Exploration of strategies for facilitating the reading comprehension of high-functioning students with autism spectrum disorders. J Autism Dev Disord. 04. 2004;34(2):115-27. X-1. [pmid: 15162931].
2510 O’Connor K, Hamm JP, Kirk IJ. The Neurophysiological Correlates of Face Processing in Adults and Children with Asperger’s Syndrome. Brain and Cognition. 10. 2005;59(1):82-95. X-1, X-4. [pmid: 16009478].
2511 Odom SL, Strain PS. A comparison of peer-initiation and teacher-antecedent interventions for promoting reciprocal social interaction of autistic preschoolers. Journal of Applied Behavior Analysis. Spr. 1986;19(1):59-71. X-3, X-10. [pmid: 3710949].
2512 Odom SL, Watts E. Reducing teacher prompts in peer-mediated interventions for young children with autism. The Journal of Special Education. Spr. 1991;25(1):26-43. X-10.
2513 Oertel W, Poewe W, Wolters E, et al. Effects of rivastigmine on tremor and other motor symptoms in patients with Parkinson’s disease dementia: a retrospective analysis of a double-blind trial and an open-label extension. Drug Saf. 2008;31(1):79-94. X-1, X-4. [pmid: 18095748].
2514 Ogawa T, Sugiyama A, Ishiwa S, et al. Ontogenic development of EEG-asymmetry in early infantile autism. Brain Dev. 1982;4(6):439-49. X-4, X-10. [pmid: 7168481].
2515 Ogletree BT. Communication intervention for a preverbal child with autism: A case study. Focus on Autistic Behavior. 04. 1992;7(1):1-12. X-10.
2516 Ogletree BT, Crawford K. Contemplating the Communicative Value of Objects: Establishing Iconic and Indexical Object Experiences with Individuals with Severe Intellectual Disabilities. Focus on Autism and Other Developmental Disabilities. 2009;24(4):248-251. X-1, X-2, X-3, X-4.
2517 Ogletree BT, Fischer MA, Sprouse J. An innovative language treatment for a child with high-functioning autism. Focus on Autistic Behavior. 08. 1995;10(3):1-10. X-3, X-10.
2518 Ogletree BT, Hamtil A, Solberg L, et al. Facilitated communication: Illustration of a naturalistic validation method. Focus on Autistic Behavior. 10. 1993;8(4):1-10. X-3, X-10.
2519 Ogletree BT, Oren T, Fischer MA. Examining Effective Intervention Practices for Communication Impairment in Autism Spectrum Disorder. Exceptionality. 11. 2007;15(4):233-247. X-1, X-2, X-3.
2520 O’Hara J. Psychodynamic work and mental handicap: Observations of an autistic child. Mental Handicap. 03. 1993;21(1):32-34. X-3, X-10.
2521 O’Hare AE, Quew R, Aitken K. The identification of autism in children referred to a tertiary speech and language clinic and the implications for service delivery. Autism. 06. 1998;2(2):171-180. X-4, X-10.
2522 Ohtake Y, Yanagihara M, Nakaya A, et al. Repair Strategies Used by Elementary-Age Beginning Communicators with Autism: A Preliminary Descriptive Study. Focus on Autism and Other Developmental Disabilities. Fall. 2005;20(3):158-168. X-3, X-4.
2523 Okada S, Ohtake Y, Yanagihara M. Effects of Perspective Sentences in Social Stories[TM] on Improving the Adaptive Behaviors of Students with Autism Spectrum Disorders and Related Disabilities. Education and Training in Developmental Disabilities. 03. 2008;43(1):46-60. X-3.
2524 Oke NJ, Schreibman L. Training social initiations to a high-functioning autistic child: assessment of collateral behavior change and generalization in a case study. J Autism Dev Disord. 12. 1990;20(4):479-97. X-10. [pmid: 2279969].
2525 Olejnik L. Understanding autism. How to appropriately & safely approach, assess & manage autistic patients. JEMS. 06. 2004;29(6):56-61. 64. X-1, X-2, X-3, X-4.
2526 Olesker W. Treatment of a boy with atypical ego development. The Psychoanalytic Study of the Child. 1999;54:25-46. X-3, X-10. [pmid: 10748627].
2527 Olfson M, Blanco C, Liu L, et al. National trends in the outpatient treatment of children and adolescents with antipsychotic drugs. Arch Gen Psychiatry. 06. 2006;63(6):679-85. X-2, X-3, X-4. [pmid: 16754841].
2528 Olive M. Assessment and Intervention for Young Children with Nonphysiological Feeding Concerns. Young Exceptional Children. 2004;7(4):10-19. X-1, X-2, X-3, X-4.
2529 Olive ML, de la Cruz B, Davis TN, et al. The effects of enhanced milieu teaching and a voice output communication aid on the requesting of three children with autism. J Autism Dev Disord. 09. 2007;37(8):1505-13. X-3. [pmid: 17066309].
2530 Olive ML, Lang RB, Davis TN. An analysis of the effects of functional communication and a Voice Output Communication Aid for a child with autism spectrum disorder. Research in Autism Spectrum Disorders. 04–06. 2008;2(2):223-236. X-3.
2531 Oliver L, Johnson A. Autism Disorders. NCSL Legisbrief. 11–12. 2004;12(46):1-2. X-1, X-2, X-3, X-4.
2532 Ollendick TH, Shapiro ES, Barrett RP. Effects of vicarious reinforcement in normal and severely disturbed children. J Consult Clin Psychol. 02. 1982;50(1):63-70. X-10. [pmid: 7056921].
2533 Olley JG, Devellis RF, Devellis BM, et al. The Autism Attitude Scale for Teachers. Except Child. 02. 1981;47(5):371-2. X-4, X-10. [pmid: 7202461].
2534 Olson LJ, Moulton HJ. Use of weighted vests in pediatric occupational therapy practice. Phys Occup Ther Pediatr. 2004;24(3):45-60. X-1, X-4. [pmid: 15257968].
2535 Olsson MB, Hwang CP. Socioeconomic and psychological variables as risk and protective factors for parental well-being in families of children with intellectual disabilities. J Intellect Disabil Res. 12. 2008;52(12):1102-13. X-1, X-4. [pmid: 18507702].
2536 Oneal BJ, Reeb RN, Korte JR, et al. Assessment of home-based behavior modification programs for autistic children: reliability and validity of the behavioral summarized evaluation. J Prev Interv Community. 2006;32(1–2):25-39. X-1, X-2, X-3. [pmid: 17000600].
2537 O’Neill RE, Sweetland-Baker M. Brief report: An assessment of stimulus generalization and contingency effects in functional communication training with two students with autism. Journal of Autism and Developmental Disorders. 04. 2001;31(2):235-240. X-3. [pmid: 11450822].
2538 Onion CW, Dutton CE, Walley T, et al. Local clinical guidelines: description and evaluation of a participative method for their development and implementation. Fam Pract. 02. 1996;13(1):28-34. X-1, X-4, X-10. [pmid: 8671101].
2539 Ooi YP, Lam CM, Sung M, et al. Effects of cognitive-behavioural therapy on anxiety for children with high-functioning autistic spectrum disorders. Singapore Med J. 03. 2008;49(3):215-20. X-3. [pmid: 18363003].
2540 Opler LA, White L, Caton CL, et al. Gender differences in the relationship of homelessness to symptom severity, substance abuse, and neuroleptic noncompliance in schizophrenia. J Nerv Ment Dis. 07. 2001;189(7):449-56. X-1, X-4. [pmid: 11504322].
2541 Oram Cardy JE, Ferrari P, Flagg EJ, et al. Prominence of M50 auditory evoked response over M100 in childhood and autism. Neuroreport. 08. 26. 2004;15(12):1867-70. X-4. [pmid: 15305126].
2542 Oram Cardy JE, Flagg EJ, Roberts W, et al. Magnetoencephalography identifies rapid temporal processing deficit in autism and language impairment. Neuroreport. 03. 15. 2005;16(4):329-32. X-4. [pmid: 15729132].
2543 Oram Cardy JE, Flagg EJ, Roberts W, et al. Auditory evoked fields predict language ability and impairment in children. Int J Psychophysiol. 05. 2008;68(2):170-5. X-4. [pmid: 18304666].
2544 O’Reilly Mark F, Sigafoos J, et al. A Preliminary Examination of the Evocative Effects of the Establishing Operation. Journal of Applied Behavior Analysis. Sum. 2006;39(2):239-242. X-3. [pmid: 16813045].
2545 O’Reilly MF, Edrisinha C, Sigafoos J, et al. Isolating the evocative and abative effects of an establishing operation on challenging behavior. Behavioral Interventions. 07. 2006;21(3):195-204. X-1, X-3.
2546 Orekhova EV, Stroganova TA, Prokofyev AO, et al. Sensory gating in young children with autism: relation to age, IQ, and EEG gamma oscillations. Neurosci Lett. 03. 28. 2008;434(2):218-23. X-4. [pmid: 18313850].
2547 O’Riordan M, Passetti F. Discrimination in autism within different sensory modalities. J Autism Dev Disord. 07. 2006;36(5):665-75. X-4. [pmid: 16639532].
2548 Orme DM. A Qualitative Examination of Mothers’ Resolution or Non-Resolution of Their Children’s Disability of Down Syndrome or Autism Using a Cognitive Intervention. Qualitative Report. 09. 2005;10(3):561-592. X-1, X-3, X-4.
2549 Ornitz EM, Lane SJ, Sugiyama T, et al. Startle modulation studies in autism. J Autism Dev Disord. 12. 1993;23(4):619-37. X-4, X-10. [pmid: 8106303].
2550 Orsmond GI, Seltzer MM. Siblings of Individuals with Autism or Down Syndrome: Effects on Adult Lives. Journal of Intellectual Disability Research. 09. 2007;51(9):682-696. X-1, X-4. [pmid: 17845237].
2551 O’Shea TM, Allred EN, Dammann O, et al. The ELGAN study of the brain and related disorders in extremely low gestational age newborns. Early Hum Dev. 11. 2009;85(11):719-25. X-1, X-4. [pmid: 19765918].
2552 Ospina MB, Krebs Seida J, Clark B, et al. Behavioural and developmental interventions for autism spectrum disorder: a clinical systematic review. PLoS One. 2008;3(11):e3755. X-2. [pmid: 19015734].
2553 Ostryn C, Wolfe PS, Rusch FR. A Review and Analysis of the Picture Exchange Communication System (PECS) for Individuals With Autism Spectrum Disorders Using a Paradigm of Communication Competence. Research and Practice for Persons with Severe Disabilities. 2008;33(1–2):13-24. X-1, X-2.
2554 Oswald DP. Facilitator influence in facilitated communication. Journal of Behavioral Education. 06. 1994;4(2):191-199. X-10.
2555 Oswald DP, Ollendick TH. Role taking and social competence in autism and mental retardation. J Autism Dev Disord. 03. 1989;19(1):119-27. X-4, X-10. [pmid: 2708295].
2556 Oswald DP, Sonenklar NA. Medication use among children with autism spectrum disorders. J Child Adolesc Psychopharmacol. 06. 2007;17(3):348-55. X-4. [pmid: 17630868].
2557 Ouellette-Kuntz H, Coo H, Lloyd JEV, et al. Trends in Special Education Code Assignment for Autism: Implications for Prevalence Estimates. Journal of Autism and Developmental Disorders. 11. 2007;37(10):1941-1948. X-4. [pmid: 17216561].
2558 Owen-DeSchryver JS, Carr EG, Cale SI, et al. Promoting Social Interactions between Students with Autism Spectrum Disorders and Their Peers in Inclusive School Settings. Focus on Autism and Other Developmental Disabilities. 2008;23(1):15-28. X-3.
2559 Owens JA, Rosen CL, Mindell JA. Medication use in the treatment of pediatric insomnia: results of a survey of community-based pediatricians. Pediatrics. 05. 2003;111(5 Pt 1):e628-35. X-1, X-4. [pmid: 12728122].
2560 Owens SR. Injection of confidence. The recent controversy in the UK has led to falling MMR vaccination rates. EMBO Rep. 05. 2002;3(5):406-9. X-1, X-2, X-3, X-4. [pmid: 11991943].
2561 Owley T, Salt J, Guter S, et al. A prospective, open-label trial of memantine in the treatment of cognitive, behavioral, and memory dysfunction in pervasive developmental disorders. J Child Adolesc Psychopharmacol. 10. 2006;16(5):517-24. X-3. [pmid: 17069541].
2562 Owley T, Walton L, Salt J, et al. An open-label trial of escitalopram in pervasive developmental disorders. J Am Acad Child Adolesc Psychiatry. 04. 2005;44(4):343-8. X-3. [pmid: 15782081].
2563 Ozbayrak KR. Sertraline in PDD. Journal of the American Academy of Child & Adolescent Psychiatry. 01. 1997;36(1):7-8. X-3, X-10. [pmid: 9000775].
2564 Ozdemir S. The effectiveness of social stories on decreasing disruptive behaviors of children with autism: three case studies. J Autism Dev Disord. 10. 2008;38(9):1689-96. X-3. [pmid: 18373187].
2565 Ozonoff S, Cathcart K. Effectiveness of a home program intervention for young children with autism. J Autism Dev Disord. 02. 1998;28(1):25-32. X-10. [pmid: 9546299].
2566 Ozonoff S, Miller JN. Teaching theory of mind: a new approach to social skills training for individuals with autism. J Autism Dev Disord. 08. 1995;25(4):415-33. X-3, X-10. [pmid: 7592252].
2567 PÃ©rez-GonzÃ¡lez LA, Williams G. Comprehensive program for teaching skills to children with autism. Psychology in Spain. 2006;10:37-51. X-3.
2568 Paavonen EJ, Nieminen-von Wendt T, Vanhala R, et al. Effectiveness of melatonin in the treatment of sleep disturbances in children with Asperger disorder. J Child Adolesc Psychopharmacol. Spring. 2003;13(1):83-95. X-3. [pmid: 12804129].
2569 Padhye U. Excess dietary iron is the root cause for increase in childhood autism and allergies. Med Hypotheses. 08. 2003;61(2):220-2. X-2, X-3, X-4. [pmid: 12888307].
2570 Page T. Metabolic approaches to the treatment of autism spectrum disorders. J Autism Dev Disord. 10. 2000;30(5):463-9. X-2, X-3. [pmid: 11098885].
2571 Page T, Moseley C. Metabolic treatment of hyperuricosuric autism. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 02. 2002;26(2):397-400. X-3. [pmid: 11817520].
2572 Pagonabarraga J, Kulisevsky J, Llebaria G, et al. Parkinson’s disease-cognitive rating scale: a new cognitive scale specific for Parkinson’s disease. Mov Disord. 05. 15. 2008;23(7):998-1005. X-1, X-2, X-3, X-4. [pmid: 18381647].
2573 Pagonabarraga J, Llebaria G, Garcia-Sanchez C, et al. A prospective study of delusional misidentification syndromes in Parkinson’s disease with dementia. Mov Disord. 02. 15. 2008;23(3):443-8. X-1, X-4. [pmid: 18076112].
2574 Paisey TJ, Fox S, Curran C, et al. Case study: Reinforcement control of severe aggression exhibited by a child with autism in a family home. Behavioral Residential Treatment. 10. 1991;6(4):289-302. X-10.
2575 Pakenham KI, Samios C, Sofronoff K. Adjustment in Mothers of Children with Asperger Syndrome: An Application of the Double ABCX Model of Family Adjustment. Autism The International Journal of Research and Practice. 05. 2005;9(2):191-212. X-1, X-4. [pmid: 15857862].
2576 Pakenham KI, Sofronoff K, Samios C. Finding meaning in parenting a child with Asperger syndrome: correlates of sense making and benefit finding. Res Dev Disabil. 05–06. 2004;25(3):245-64. X-1, X-4. [pmid: 15134791].
2577 Pakrasi S, Mukaetova-Ladinska EB, McKeith IG, et al. Clinical predictors of response to Acetyl Cholinesterase Inhibitors: experience from routine clinical use in Newcastle. Int J Geriatr Psychiatry. 10. 2003;18(10):879-86. X-4. [pmid: 14533120].
2578 Palermo MT. Preventing filicide in families with autistic children. Int J Offender Ther Comp Criminol. 02. 2003;47(1):47-57. X-2, X-3, X-4. [pmid: 12613431].
2579 Palkovitz RJ, Wiesenfeld AR. Differential autonomic responses of autistic and normal children. J Autism Dev Disord. 09. 1980;10(3):347-60. X-3, X-4, X-10. [pmid: 6927661].
2580 Pallanti S, Lassi S, La Malfa G, et al. Short report: Autistic gastrointestinal and eating symptoms treated with secretin: A subtype of autism. Clinical Practice and Epidemiology in Mental Health. 2005;1. X-3.
2581 Palmen A, Didden R, Arts M. Improving question asking in high-functioning adolescents with autism spectrum disorders: effectiveness of small-group training. Autism. 01. 2008;12(1):83-98. X-3. [pmid: 18178598].
2582 Pan C-Y. Objectively Measured Physical Activity between Children with Autism Spectrum Disorders and Children without Disabilities during Inclusive Recess Settings in Taiwan. Journal of Autism and Developmental Disorders. 08. 2008;38(7):1292-1301. X-4. [pmid: 18157623].
2583 Pan C-Y. School Time Physical Activity of Students with and without Autism Spectrum Disorders during PE and Recess. Adapted Physical Activity Quarterly. 10. 2008;25(4):308-321. X-4. [pmid: 18955747].
2584 Pan C-Y, Frey GC. Physical Activity Patterns in Youth with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 07. 2006;36(5):597-606. X-4. [pmid: 16652237].
2585 Pandolfi V, Magyar CI, Dill CA. Confirmatory Factor Analysis of the Child Behavior Checklist 1.5–5 in a Sample of Children with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 07. 2009;39(7):986-995. X-4. [pmid: 19263208].
2586 Panerai S, Ferrante L, Zingale M. Benefits of the Treatment and Education of Autistic and Communication Handicapped Children (TEACCH) programme as compared with a non-specific approach. J Intellect Disabil Res. 05. 2002;46(Pt 4):318-27. X-6. [pmid: 12000583].
2587 Panksepp J, Lensing P. Brief report: a synopsis of an open-trial of naltrexone treatment of autism with four children. J Autism Dev Disord. 06. 1991;21(2):243-9. X-3, X-10. [pmid: 1864831].
2588 Panksepp J, Lensing P. A synopsis of an open-trial of naltrexone treatment of autism with four children. Journal of Autism and Developmental Disorders. 06. 1991;21(2):243-249. X-3, X-10. [pmid: 1864831].
2589 Pansegrouw I, Alant E. Communication intervention in an adolescent with profound cognitive impairment and autistic features. S Afr J Commun Disord. 1996;43:63-75. X-3, X-10. [pmid: 9265844].
2590 Panyan MV. Computer technology for autistic students. J Autism Dev Disord. 12. 1984;14(4):375-82. X-1, X-2, X-10. [pmid: 6549182].
2591 Papavramidis TS, Duros V, Michalopoulos A, et al. Intra-abdominal pressure alterations after large pancreatic pseudocyst transcutaneous drainage. BMC Gastroenterol. 2009;9:42. X-1, X-2, X-3, X-4. [pmid: 19500396].
2592 Pardew EM, Bunse C. Enhancing Interaction through Positive Touch. Young Exceptional Children. 2005;8(2):21-29. X-3.
2593 Pareek M, Pattison HM. The two-dose measles, mumps, and rubella (MMR) immunisation schedule: factors affecting maternal intention to vaccinate. Br J Gen Pract. 12. 2000;50(461):969-71. X-1, X-4. [pmid: 11224968].
2594 Pares N, Carreras A, Durany J, et al. Starting research in interaction design with visuals for low-functioning children in the autistic spectrum: a protocol. Cyberpsychol Behav. 04. 2006;9(2):218-23. X-1, X-2, X-3, X-4. [pmid: 16640483].
2595 Pares N, Masri P, van Wolferen G, et al. Achieving dialogue with children with severe autism in an adaptive multisensory interaction: the “MEDIAte” project. IEEE Trans Vis Comput Graph. 11–12. 2005;11(6):734-43. X-1, X-2, X-3, X-4. [pmid: 16270865].
2596 Parette P, Chuang SJL, Huer MB. First-Generation Chinese American Families’ Attitudes Regarding Disabilities and Educational Interventions. Focus on Autism and Other Developmental Disabilities. June. 2004;19(2):114-123. X-1, X-3, X-4.
2597 Park JB, Watthanaaphisit T, Riew KD. Timing of development of adjacent-level ossification after anterior cervical arthrodesis with plates. Spine J. 11–12. 2007;7(6):633-6. X-1, X-4. [pmid: 17998121].
2598 Park YD. The effects of vagus nerve stimulation therapy on patients with intractable seizures and either Landau-Kleffner syndrome or autism. Epilepsy Behav. 06. 2003;4(3):286-90. X-1, X-3. [pmid: 12791330].
2599 Parker JP, Li Z, Damberg CL, et al. Administrative versus clinical data for coronary artery bypass graft surgery report cards: the view from California. Med Care. 07. 2006;44(7):687-95. X-1, X-3, X-4. [pmid: 16799364].
2600 Parkinson GM. Pragmatic difficulties in children with autism associated with childhood epilepsy. Pediatr Rehabil. 07–09. 2006;9(3):229-46. X-4. [pmid: 17050401].
2601 Parnetti L, Ban TA, Senin U. Glycosaminoglycan polysulfate in primary degenerative dementia. Pilot study of biologic and clinical effects. Neuropsychobiology. 1995;31(2):76-80. X-1, X-3, X-4, X-10. [pmid: 7539116].
2602 Parr J. Autism. Clin Evid (Online). 2008:2008. X-2.
2603 Parsons S, Mitchell P. The potential of virtual reality in social skills training for people with autistic spectrum disorders. J Intellect Disabil Res. 06. 2002;46(Pt 5):430-43. X-1, X-2, X-3. [pmid: 12031025].
2604 Parsons S, Mitchell P, Leonard A. The use and understanding of virtual environments by adolescents with autistic spectrum disorders. J Autism Dev Disord. 08. 2004;34(4):449-66. X-1, X-3, X-4. [pmid: 15449520].
2605 Parteli L. Aesthetic listening: Contributions of dance/movement therapy to the psychic understanding of motor stereotypes and distortions in autism and psychosis in childhood and adolescence. The Arts in Psychotherapy. Special Issue: European Consortium for Arts Therapy Education (ECArTE). 1995;22(3):241-247. X-1, X-2, X-3, X-4, X-10.
2606 Pary RJ. Acute psychiatric hospital admissions of adults and elderly adults with mental retardation. Am J Ment Retard. 11. 1993;98(3):434-6. X-1, X-3, X-4, X-10. [pmid: 8292320].
2607 Pasco G, Gordon RK, Howlin P, et al. The Classroom Observation Schedule to Measure Intentional Communication (COSMIC): an observational measure of the intentional communication of children with autism in an unstructured classroom setting. J Autism Dev Disord. 11. 2008;38(10):1807-18. X-4. [pmid: 18401692].
2608 Pasiali V. The use of prescriptive therapeutic songs in a home-based environment to promote social skills acquisition by children with autism: Three case studies. Music Therapy Perspectives. 2004;22(1):11-20. X-3.
2609 Patel K, Curtis LT. A comprehensive approach to treating autism and attention-deficit hyperactivity disorder: a prepilot study. J Altern Complement Med. 12. 2007;13(10):1091-7. X-3. [pmid: 18166120].
2610 Patel MR, Carr JE, Dozier CL. On the role of stimulus preference assessment in the evaluation of contingent access to stimuli associated with stereotypy during behavioral acquisition. Behavioral Interventions. 11. 1998;13(4):269-274. X-3, X-10.
2611 Patel MR, Carr JE, Kim C, et al. Functional Analysis of Aberrant Behavior Maintained by Automatic Reinforcement: Assessments of Specific Sensory Reinforcers. Research in Developmental Disabilities Journal Citation. 09–10. 2000;21(5):393-407. Publisher:. 2000 Pub Types: Journal Articles; Reports - Research. X-1, X-3.
2612 Patel MR, Piazza CC, Kelly ML, et al. Using a fading procedure to increase fluid consumption in a child with feeding problems. Journal of Applied Behavior Analysis. Fal. 2001;34(3):357-360. X-3. [pmid: 11678534].
2613 Patel MR, Piazza CC, Martinez CJ, et al. An evaluation of two differential reinforcement procedures with escape extinction to treat food refusal. J Appl Behav Anal. Winter. 2002;35(4):363-74. X-3. [pmid: 12555908].
2614 Paterson CR, Arco L. Using video modeling for generalizing toy play in children with autism. Behav Modif. 09. 2007;31(5):660-81. X-3. [pmid: 17699123].
2615 Patil AA, Andrews R. Surgical treatment of autistic epileptiform regression. Journal of Epilepsy. 11–12. 1998;11(6):368-373. X-3, X-10.
2616 Patterson A, Rafferty A. Making it to work: towards employment for the young adult with autism. Int J Lang Commun Disord. 2001;36(Suppl):475-80. X-1, X-3, X-4. [pmid: 11340835].
2617 Paul AS, Frea WD. The importance of understanding the goals of the family. Journal of Positive Behavior Interventions. Win. 2002;4(1):61-63. X-3.
2618 Paul C, Williams KE, Riegel K, et al. Combining repeated taste exposure and escape prevention: An intervention for the treatment of extreme food selectivity. Appetite. 11. 2007;49(3):708-711. X-3. [pmid: 17920728].
2619 Paul R. Parents ask: Am I risking autism if I vaccinate my children?. J Autism Dev Disord. 06. 2009;39(6):962-3. X-4. [pmid: 19363650].
2620 Paul R, Chawarska K, Cicchetti D, et al. Language outcomes of toddlers with autism spectrum disorders: a two year follow-up. Autism Res. 04. 2008;1(2):97-107. X-4. [pmid: 19360656].
2621 Paul R, Cohen DJ. Outcomes of severe disorders of language acquisition. J Autism Dev Disord. 12. 1984;14(4):405-21. X-1, X-4, X-10. [pmid: 6084003].
2622 Paul R, Miles S, Cicchetti D, et al. Adaptive behavior in autism and Pervasive Developmental Disorder-Not Otherwise Specified: microanalysis of scores on the Vineland Adaptive Behavior Scales. J Autism Dev Disord. 04. 2004;34(2):223-8. X-4. [pmid: 15162940].
2623 Paul R, Shriberg LD, McSweeny J, et al. Brief Report: Relations between Prosodic Performance and Communication and Socialization Ratings in High Functioning Speakers with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 12. 2005;35(6):861-869. X-4. [pmid: 16283080].
2624 Paylor R, Yuva-Paylor LA, Nelson DL, et al. Reversal of sensorimotor gating abnormalities in Fmr1 knockout mice carrying a human Fmr1 transgene. Behav Neurosci. 12. 2008;122(6):1371-7. X-1, X-3, X-4. [pmid: 19045956].
2625 Pearson DA, Lane DM, Santos CW, et al. Effects of methylphenidate treatment in children with mental retardation and ADHD: individual variation in medication response. J Am Acad Child Adolesc Psychiatry. 06. 2004;43(6):686-98. X-1, X-4. [pmid: 15167085].
2626 Peck CA. Increasing opportunities for social control by children with autism and severe handicaps: Effects on student behavior and perceived classroom climate. Journal of the Association for Persons with Severe Handicaps. Win. 1985;10(4):183-193. X-10.
2627 Peele PB, Lave JR, Kelleher KJ. Exclusions and limitations in children’s behavioral health care coverage. Psychiatr Serv. 05. 2002;53(5):591-4. X-1, X-3, X-4. [pmid: 11986509].
2628 Pelios LV, MacDuff GS, Axelrod S. The effects of a treatment package in establishing independent academic work skills in children with autism. Education & Treatment of Children. 02. 2003;26(1):1-21. X-3.
2629 Peng CZ, Hatlestad P, Klug MG, et al. Health care costs and utilization rates for children with pervasive developmental disorders in North Dakota from 1998 to 2004: impact on Medicaid. J Child Neurol. 02. 2009;24(2):140-7. X-4. [pmid: 19182149].
2630 Penn CL. Vaccine safety & immunization information. J Ark Med Soc. 06. 2006;102(12):322-4. X-4. [pmid: 16776306].
2631 Pennington L, James P, McNally R, et al. Analysis of compositional data in communication disorders research. J Commun Disord. 01–02. 2009;42(1):18-28. X-1, X-2, X-3, X-4. [pmid: 18723184].
2632 Penrod B, Wallace MD, Dyer EJ. Assessing potency of high- and low-preference reinforcers with respect to response rate and response patterns. J Appl Behav Anal. Summer. 2008;41(2):177-88. X-3. [pmid: 18595282].
2633 Pepperberg IM, Sherman D. Proposed use of two-part interactive modeling as a means to increase functional skills in children with a variety of disabilities. Teach Learn Med. Fall. 2000;12(4):213-20. X-3. [pmid: 11273372].
2634 Perel I. Deinstitutionalization at a large facility: a focus on treatment. Res Dev Disabil. 1992;13(1):81-6. X-2, X-3, X-4, X-10. [pmid: 1585024].
2635 Perez-Gonzalez LA, Williams G. Multicomponent procedure to teach conditional discriminations to children with autism. Am J Ment Retard. 07. 2002;107(4):293-301. X-3. [pmid: 12069648].
2636 Perez-Soler R, Yang LY, Drewinko B, et al. Increased cytotoxicity and reversal of resistance to cis-diamminedichloro-platinum(II) with entrapment of cis-Bis-neodecanoato-trans-R,R-1,2-diaminocyclohexaneplatinum (II) in multilamellar lipid vesicles. Cancer Res. 08. 15. 1988;48(16):4509-12. X-1, X-3, X-4, X-10. [pmid: 3396003].
2637 Perquin M, Michel GH, de Beaufort C, et al. Changes in diabetes prevalence and treatment in the last ten years in Luxembourg. A lesson from the United Kingdom prospective diabetes study?. Diabetes Metab. 11. 2005;31(5):499-502. X-1, X-4. [pmid: 16357795].
2638 Perriol MP, Dujardin K, Derambure P, et al. Disturbance of sensory filtering in dementia with Lewy bodies: comparison with Parkinson’s disease dementia and Alzheimer’s disease. J Neurol Neurosurg Psychiatry. 01. 2005;76(1):106-8. X-1, X-3, X-4. [pmid: 15608006].
2639 Perry A, Bryson S, Bebko J. Brief report: Degree of facilitator influence in facilitated communication as a function of facilitator characteristics, attitudes, and beliefs. J Autism Dev Disord. 02. 1998;28(1):87-90. X-10. [pmid: 9546307].
2640 Perry A, Factor DC. Psychometric validity and clinical usefulness of the Vineland Adaptive Behavior Scales and the AAMD Adaptive Behavior Scale for an autistic sample. J Autism Dev Disord. 03. 1989;19(1):41-55. X-4, X-10. [pmid: 2708303].
2641 Perry A, Flanagan HE, Dunn Geier J, et al. Brief report: the Vineland Adaptive Behavior Scales in young children with autism spectrum disorders at different cognitive levels. J Autism Dev Disord. 07. 2009;39(7):1066-78. X-4. [pmid: 19234777].
2642 Perry DW, Marston GM, Hinder SA, et al. The phenomenology of depressive illness in people with a learning disability and autism. Autism. 09. 2001;5(3):265-75. X-1, X-2, X-3, X-4. [pmid: 11708586].
2643 Perry R, Campbell M, Adams P, et al. Long-term efficacy of haloperidol in autistic children: continuous versus discontinuous drug administration. J Am Acad Child Adolesc Psychiatry. 01. 1989;28(1):87-92. X-10. [pmid: 2914841].
2644 Perry R, Campbell M, Green WH, et al. Neuroleptic-related dyskinesias in autistic children: a prospective study. Psychopharmacol Bull. 1985;21(1):140-3. X-10. [pmid: 3885290].
2645 Perry R, Cohen I, DeCarlo R. Case study: Deterioration, autism, and recovery in two siblings. Journal of the American Academy of Child & Adolescent Psychiatry. 02. 1995;34(2):232-237. X-3, X-10. [pmid: 7896656].
2646 Perry R, Nobler MS, Campbell M. Tourette-like symptoms associated with neuroleptic therapy in an autistic child. Journal of the American Academy of Child & Adolescent Psychiatry. 01. 1989;28(1):93-96. X-3, X-10. [pmid: 2914842].
2647 Perry R, Pataki C, Munoz-Silva DM, et al. Risperidone in children and adolescents with pervasive developmental disorder: pilot trial and follow-up. J Child Adolesc Psychopharmacol. 1997;7(3):167-79. X-10. [pmid: 9466234].
2648 Perry W, Minassian A, Lopez B, et al. Sensorimotor gating deficits in adults with autism. Biol Psychiatry. 02. 15. 2007;61(4):482-6. X-1, X-4. [pmid: 16460695].
2649 Persson B. Brief report: A longitudinal study of quality of life and independence among adult men with autism. J Autism Dev Disord. 02. 2000;30(1):61-6. X-1, X-3, X-4. [pmid: 10819121].
2650 Persson B, Nordstrom B, Petersson K, et al. Screening for infants with developmental deficits and/or autism: a Swedish pilot study. J Pediatr Nurs. 08. 2006;21(4):313-24. X-4. [pmid: 16843217].
2651 Peterson CC. Theory-of-mind development in oral deaf children with cochlear implants or conventional hearing aids. J Child Psychol Psychiatry. 09. 2004;45(6):1096-106. X-4. [pmid: 15257666].
2652 Peterson CC. Mind and body: concepts of human cognition, physiology and false belief in children with autism or typical development. J Autism Dev Disord. 08. 2005;35(4):487-97. X-4. [pmid: 16134034].
2653 Peterson CC, Garnett M, Kelly A, et al. Everyday social and conversation applications of theory-of-mind understanding by children with autism-spectrum disorders or typical development. Eur Child Adolesc Psychiatry. 02. 2009;18(2):105-15. X-4. [pmid: 18810310].
2654 Peterson CC, Siegal M. Deafness, conversation and theory of mind. J Child Psychol Psychiatry. 03. 1995;36(3):459-74. X-1, X-3, X-4, X-10. [pmid: 7782409].
2655 Peterson CC, Siegal M. Domain specificity and everyday biological, physical, and psychological thinking in normal, autistic, and deaf children. New Dir Child Dev. Spring. 1997;(75):55-70. X-10.
2656 Peterson CC, Slaughter V. Theory of Mind (ToM) in Children with Autism or Typical Development: Links between Eye-Reading and False Belief Understanding. Research in Autism Spectrum Disorders. 04–06. 2009;3(2):462-473. X-4.
2657 Peterson CC, Slaughter VP, Paynter J. Social maturity and theory of mind in typically developing children and those on the autism spectrum. J Child Psychol Psychiatry. 12. 2007;48(12):1243-50. X-4. [pmid: 18093030].
2658 Peterson L, McLaughlin TF, Weber KP, et al. The effects of model, lead, and test technique with visual prompts paired with a fading procedure to teach “where” to a 13-year-old echolalic boy with autism. Journal of Developmental and Physical Disabilities. 02. 2008;20(1):31-39. X-1, X-3.
2659 Peterson SMP, Caniglia C, Royster AJ. Application of choice-making intervention for a student with multiply maintained problem behavior. Focus on Autism and Other Developmental Disabilities. Win. 2001;16(4):240-246. X-3.
2660 Peters-Scheffer N, Didden R, Green VA, et al. The behavior flexibility rating scale-revised (BFRS-R): factor analysis, internal consistency, inter-rater and intra-rater reliability, and convergent validity. Res Dev Disabil. 09–10. 2008;29(5):398-407. X-4. [pmid: 17826945].
2661 Petrovic M, Roberts R, Ramsay M. Second dose of measles, mumps, and rubella vaccine: questionnaire survey of health professionals. BMJ. 01. 13. 2001;322(7278):82-85. X-1, X-3, X-4. [pmid: 11154622].
2662 Peyton RT, Lindauer SE, ichman DM. The Effects of Directive and Nondirective Prompts on Noncompliant Vocal Behavior Exhibited by a Child with Autism. Journal of Applied Behavior Analysis. Sum. 2005;38(2):251. X-3. [pmid: 16033173].
2663 Pfeiffer B, Kinnealey M, Reed C, et al. Sensory modulation and affective disorders in children and adolescents with Asperger’s disorder. Am J Occup Ther. 05–06. 2005;59(3):335-45. X-4. [pmid: 15969281].
2664 Pfeiffer SI, Nelson DD. The cutting edge in services for people with autism. J Autism Dev Disord. 03. 1992;22(1):95-105. X-1, X-3, X-4, X-10. [pmid: 1592767].
2665 Phadraig BM. Towards Inclusion: The Development of Provision for Children with Special Educational Needs in Ireland from 1991 to 2004. Irish Educational Studies. 09. 2007;26(3):289-300. X-1, X-2, X-3, X-4.
2666 Phancharoen S. Rett syndrome in Thai female girls: clinical studies. J Med Assoc Thai. 06. 2001;84(Suppl 1):S57-60. X-1, X-3, X-4. [pmid: 11529381].
2667 Phelan S, Steinke L, Mandich A. Exploring a cognitive intervention for children with pervasive developmental disorder. Canadian Journal of Occupational Therapy. 02. 2009;76(1):23-28. X-3.
2668 Phetrasuwan S, Miles MS, Mesibov GB, et al. Defining autism spectrum disorders. J Spec Pediatr Nurs. 07. 2009;14(3):206-9. X-1, X-2, X-3, X-4. [pmid: 19614831].
2669 Philip RC, Whalley HC, Stanfield AC, et al. Deficits in facial, body movement and vocal emotional processing in autism spectrum disorders. Psychol Med. 01. 2010;27:1-11. X-1, X-3, X-4.
2670 Philippart M. Clinical recognition of Rett syndrome. Am J Med Genet Suppl. 1986;1:111-8. X-1, X-2, X-3, X-4, X-10. [pmid: 3087171].
2671 Phillips L, Appleton RE. Systematic review of melatonin treatment in children with neurodevelopmental disabilities and sleep impairment. Dev Med Child Neurol. 11. 2004;46(11):771-5. X-1, X-2, X-3, X-4. [pmid: 15540639].
2672 Piazza CC, Adelinis JD, Hanley GP, et al. An evaluation of the effects of matched stimuli on behaviors maintained by automatic reinforcement. J Appl Behav Anal. Spring. 2000;33(1):13-27. X-1, X-3, X-4. [pmid: 10738949].
2673 Piazza CC, Fisher WW, Hagopian LP, et al. Using a choice assessment to predict reinforcer effectiveness. J Appl Behav Anal. Spring. 1996;29(1):1-9. X-3, X-10. [pmid: 8881340].
2674 Piazza CC, Fisher WW, Hanley GP, et al. Treatment of pica through multiple analyses of its reinforcing functions. Journal of Applied Behavior Analysis. Sum. 1998;31(2):165-189. X-3, X-10. [pmid: 9652098].
2675 Piazza CC, Hagopian LP, Hughes CR, et al. Using chronotherapy to treat severe sleep problems: A case study. American Journal on Mental Retardation. 01. 1998;102(4):358-366. X-3, X-10. [pmid: 9475944].
2676 Piazza CC, Hanley GP, Fisher WW. Functional analysis and treatment of cigarette pica. Journal of Applied Behavior Analysis. Win. 1996;29(4):437-450. X-1, X-3, X-10. [pmid: 8995829].
2677 Piazza CC, Moes DR, Fisher WW. Differential reinforcement of alternative behavior and demand fading in the treating fading in the treatment of escape-maintained destructive behavior. Journal of Applied Behavior Analysis. Win. 1996;29(4):569-572. X-3, X-10. [pmid: 8995837].
2678 Piazza CC, Patel MR, Santana CM, et al. An evaluation of simultaneous and sequential presentation of preferred and nonpreferred food to treat food selectivity. J Appl Behav Anal. Fall. 2002;35(3):259-70. X-3. [pmid: 12365739].
2679 Piazza CC, Roane HS, Keeney KM, et al. Varying response effort in the treatment of pica maintained by automatic reinforcement. J Appl Behav Anal. Fall. 2002;35(3):233-46. X-1, X-3, X-4. [pmid: 12365737].
2680 Pickering D, Morgan SB. Parental ratings of treatments of self-injurious behavior. Journal of Autism and Developmental Disorders. 09. 1985;15(3):303-314. X-1, X-3, X-4, X-10. [pmid: 4030663].
2681 Pierce K, Schreibman L. Increasing complex social behaviors in children with autism: Effects of peer-implemented pivotal response training. Journal of Applied Behavior Analysis. Fal. 1995;28(3):285-295. X-3, X-10. [pmid: 7592145].
2682 Pierce K, Schreibman L. Multiple peer use of pivotal response training to increase social behaviors of classmates with autism: results from trained and untrained peers. J Appl Behav Anal. Spring. 1997;30(1):157-60. X-10. [pmid: 9103991].
2683 Pierce KL, Schreibman L. Teaching daily living skills to children with autism in unsupervised settings through pictorial self-management. J Appl Behav Anal. Fall. 1994;27(3):471-81. X-3, X-10. [pmid: 7928790].
2684 Pierce-Jordan S, Lifter K. Interaction of Social and Play Behaviors in Preschoolers With and Without Pervasive Developmental Disorder. Topics in Early Childhood Special Education. 04. 2005;25(1):34-47. X-4.
2685 Pierson MR, Glaeser BC. Extension of Research on Social Skills Training Using Comic Strip Conversations to Students without Autism. Education and Training in Developmental Disabilities. 09. 2005;40(3):279-284. X-3.
2686 Piggott LR, Gdowski CL, Villanueva D, et al. Side effects of fenfluramine in autistic children. J Am Acad Child Psychiatry. 03. 1986;25(2):287-9. X-10. [pmid: 3700920].
2687 Pilebro C, Backman B. Teaching oral hygiene to children with autism. Int J Paediatr Dent. 01. 2005;15(1):1-9. X-3. [pmid: 15663439].
2688 Pilling N, McGill P, Cooper V. Characteristics and experiences of children and young people with severe intellectual disabilities and challenging behaviour attending 52-week residential special schools. J Intellect Disabil Res. 03. 2007;51(Pt 3):184-96. X-4. [pmid: 17300414].
2689 Pine E, Luby J, Abbacchi A, et al. Quantitative assessment of autistic symptomatology in preschoolers. Autism. 07. 2006;10(4):344-352. X-4. [pmid: 16908478].
2690 Pinto AF. Treating patients with autism. Emerg Med Serv. 06. 2001;30(6):78. 83. X-1, X-2, X-3, X-4.
2691 Pinto-Martin JA, Young LM, Mandell DS, et al. Screening strategies for autism spectrum disorders in pediatric primary care. Journal of Developmental & Behavioral Pediatrics. 10. 2008;29(5):345-350. X-4. [pmid: 18852608].
2692 Pioggia G, Igliozzi R, Ferro M, et al. An android for enhancing social skills and emotion recognition in people with autism. IEEE Trans Neural Syst Rehabil Eng. 12. 2005;13(4):507-15. X-3. [pmid: 16425833].
2693 Piotrowski WJ, Marczak J, Nawrocka A, et al. Inhalations of 5-ALA in photodynamic diagnosis of bronchial cancer. Monaldi Arch Chest Dis. 04–06. 2004;61(2):86-93. X-1, X-3, X-4. [pmid: 15510708].
2694 Pisalchaiyong T, Trairatvorakul C, Jirakijja J, et al. Comparison of the effectiveness of oral diazepam and midazolam for the sedation of autistic patients during dental treatment. Pediatr Dent. 05–06. 2005;27(3):198-206. X-1. [pmid: 16173223].
2695 Pitetti KH, Rendoff AD, Grover T, et al. The efficacy of a 9-month treadmill walking program on the exercise capacity and weight reduction for adolescents with severe autism. J Autism Dev Disord. 07. 2007;37(6):997-1006. X-1, X-4. [pmid: 17151799].
2696 Pizzamiglio MR, Nasti M, Piccardi L, et al. Sensory-Motor Rehabilitation in Rett Syndrome: A Case Report. Focus on Autism and Other Developmental Disabilities. 2008;23(1):49-62. X-1, X-3, X-4.
2697 Plienis AJ, Robbins FR, Dunlap G. Parent adjustment and family stress as factors in behavioral parent training for young autistic children. Journal of the Multihandicapped Person. 03. 1988;1(1):31-52. X-3, X-10.
2698 Plioplys AV. Autism: electroencephalogram abnormalities and clinical improvement with valproic acid. Arch Pediatr Adolesc Med. 02. 1994;148(2):220-2. X-10. [pmid: 8118547].
2699 Plioplys AV. Intravenous immunoglobulin treatment of children with autism. J Child Neurol. 02. 1998;13(2):79-82. X-10. [pmid: 9512308].
2700 Poewe W. Treatment of dementia with Lewy bodies and Parkinson’s disease dementia. Mov Disord. 08. 2005;20(Suppl 12):S77-82. X-1, X-4. [pmid: 16092095].
2701 Polimeni MA, Richdale AL, Francis AJ. A survey of sleep problems in autism, Asperger’s disorder and typically developing children. J Intellect Disabil Res. 04. 2005;49(Pt 4):260-8. X-4. [pmid: 15816813].
2702 Politi P, Cena H, Comelli M, et al. Behavioral effects of omega-3 fatty acid supplementation in young adults with severe autism: an open label study. Arch Med Res. 10. 2008;39(7):682-5. X-1. [pmid: 18760197].
2703 Pollak M. Speech problems in children. Practitioner. 05. 22. 1990;234(1489):542-5. 548. X-10. [pmid: 2392405].
2704 Poon L, Partika N, Bolman W. New hope in the treatment of autism in Hawaii. Hawaii Med J. 07. 1994;53(7):194-5. 199. X-10. [pmid: 7928306].
2705 Pope KK. The pervasive developmental disorder spectrum: A case illustration. Bulletin of the Menninger Clinic. Win. 1993;57(1):100-117. X-3, X-4, X-10. [pmid: 8443614].
2706 Posey DJ, Erickson CA, Stigler KA, et al. The use of selective serotonin reuptake inhibitors in autism and related disorders. J Child Adolesc Psychopharmacol. 02–04. 2006;16(1–2):181-6. X-1, X-2, X-3, X-4. [pmid: 16553538].
2707 Posey DJ, Guenin KD, Kohn AE, et al. A naturalistic open-label study of mirtazapine in autistic and other pervasive developmental disorders. J Child Adolesc Psychopharmacol. Fall. 2001;11(3):267-77. X-1. [pmid: 11642476].
2708 Posey DJ, Kem DL, Swiezy NB, et al. A pilot study of D-cycloserine in subjects with autistic disorder. Am J Psychiatry. 11. 2004;161(11):2115-7. X-1, X-3. [pmid: 15514414].
2709 Posey DJ, McDougle CJ. Treating autism spectrum disorders. Preface. Child Adolesc Psychiatr Clin N Am. 10. 2008;17(4):xv-xviii. X-1, X-2, X-3, X-4.
2710 Posey DJ, Walsh KH, Wilson GA, et al. Risperidone in the treatment of two very young children with autism. Journal of Child and Adolescent Psychopharmacology. Win. 1999;9(4):273-276. X-3, X-10. [pmid: 10630457].
2711 Posey DJ, Wiegand RE, Wilkerson J, et al. Open-label atomoxetine for attention-deficit/ hyperactivity disorder symptoms associated with high-functioning pervasive developmental disorders. J Child Adolesc Psychopharmacol. 10. 2006;16(5):599-610. X-3. [pmid: 17069548].
2712 Posserud M-B, Lundervold AJ, Gillberg C. Validation of the Autism Spectrum Screening Questionnaire in a total population sample. Journal of Autism and Developmental Disorders. 01. 2009;39(1):126-134. X-3, X-4. [pmid: 18592364].
2713 Potenza MN, Holmes JP, Kanes SJ, et al. Olanzapine treatment of children, adolescents, and adults with pervasive developmental disorders: an open-label pilot study. J Clin Psychopharmacol. 02. 1999;19(1):37-44. X-3, X-10. [pmid: 9934941].
2714 Powell SD, Jordan RR. Remediating the thinking of pupils with autism: principles into practice. J Autism Dev Disord. 09. 1992;22(3):413-8. X-2, X-10. [pmid: 1400104].
2715 Powers AR 3rd, Hillock AR, Wallace MT. Perceptual training narrows the temporal window of multisensory binding. J Neurosci. 09. 30. 2009;29(39):12265-74. X-1, X-3, X-4. [pmid: 19793985].
2716 Powers MD, Crowel RL. The educative effects of positive practice overcorrection: Acquisition, generalization, and maintenance. School Psychology Review. 1985;14(3):360-372. X-3, X-10.
2717 Pozzi M. A three-year-old boy with ADHD and Asperger’s syndrome treated with parent-child psychotherapy. Journal of the British Association of Psychotherapists (BAP). 01. 2003;41(1):16-31. X-3.
2718 Pozzi ME. The use of observation in the psychoanalytic treatment of a 12-year-old boy with Asperger’s syndrome. International Journal of Psychoanalysis. 10. 2003;84(5):1333-1349. X-3. [pmid: 14633433].
2719 Prado de Oliveria LE. Little Jeremy’s struggle with autism, schizophrenia and paranoia. International Forum of Psychoanalysis. 12. 1999;8(3–4):172-188. X-3, X-10.
2720 Prasher VP, Clarke DJ. Case report: Challenging behaviour in a young adult with Down’s syndrome and autism. British Journal of Learning Disabilities. 1996;24(4):167-169. X-1, X-3, X-10.
2721 Prather JH, Chovan WL. Normal peers’ reactions toward autistic children following a tutoring experience. Psychol Rep. 12. 1984;55(3):887-92. X-10. [pmid: 6522555].
2722 Prats JM, Garaizar C, Rua MJ, et al. Infantile spasms treated with high doses of sodium valproate: initial response and follow-up. Dev Med Child Neurol. 07. 1991;33(7):617-25. X-10. [pmid: 1879625].
2723 Preator KK, Jenson WR, Petersen PB, et al. Overcorrection and alternative response training in the reduction of an autistic child’s inappropriate touching. School Psychology Review. Win. 1984;13(1):107-110. X-3, X-10.
2724 Preece D, Jordan R. Short breaks services for children with autistic spectrum disorders: factors associated with service use and non-use. J Autism Dev Disord. 02. 2007;37(2):374-85. X-4. [pmid: 16897379].
2725 Preece PM, Mott J. Multidisciplinary assessment at a child development centre: Do we conform to recommended standards?. Child: Care, Health and Development. 09. 2006;32(5):559-563. X-4.
2726 Preis J. Strategies to Promote Adaptive Competence for Students on the Autism Spectrum. Support for Learning. 02. 2007;22(1):17-23. X-3.
2727 Preissler MA. Associative learning of pictures and words by low-functioning children with autism. Autism. 05. 2008;12(3):231-48. X-4. [pmid: 18445733].
2728 Prelock PA, Beatson J, Bitner B, et al. Interdisciplinary assessment of young children with autism spectrum disorder. Language, Speech, and Hearing Services in Schools. 07. 2003;34(3):194-202. X-1, X-2, X-3, X-4.
2729 Preston D, Carter M. A Review of the Efficacy of the Picture Exchange Communication System Intervention. Journal of Autism and Developmental Disorders. 10. 2009;39(10):1471-1486. X-1, X-2, X-3, X-4. [pmid: 19495952].
2730 Price A. Neurotherapy and specialization. Am J Occup Ther. 12. 1980;34(12):809-15. X-10. [pmid: 7282843].
2731 Price J, Roberts J, Vandergrift N, et al. Language Comprehension in Boys with Fragile X Syndrome and Boys with Down Syndrome. Journal of Intellectual Disability Research. 04. 2007;51(4):318-326. X-4. [pmid: 17326813].
2732 Prior M. Childhood autism. Aust Paediatr J. 06. 1987;23(3):147-9. X-4, X-10. [pmid: 3662977].
2733 Prior M, Cummins R. Questions about facilitated communication and autism. J Autism Dev Disord. 09. 1992;22(3):331-7. discussion 337–8. X-10. [pmid: 1400102].
2734 Prizant BM. Speech-language pathologists and autistic children: what is our role?. ASHA. 08. 1982;24(8):531-7. X-10. [pmid: 6758803].
2735 Progar PR, North ST, Bruce SS, et al. Putative behavioral history effects and aggression maintained by escape from therapists. Journal of Applied Behavior Analysis. Spr. 2001;34(1):69-72. X-1, X-3. [pmid: 11317990].
2736 Prothmann A, Albrecht K, Dietrich S, et al. Analysis of child-dog play behavior in child psychiatry. AnthrozoÃ¶s. 2005;18(1):43-58. X-4.
2737 Provost B, Heimerl S, Lopez BR. Levels of gross and fine motor development in young children with autism spectrum disorder. Phys Occup Ther Pediatr. 2007;27(3):21-36. X-4. [pmid: 17613454].
2738 Prupas A, Harvey WJ, Benjamin J. Early Intervention Aquatics: A Program for Children with Autism and Their Families. Journal of Physical Education, Recreation & Dance (JOPERD). 02. 2006;77(2):46-51. X-2, X-4.
2739 Puri BK, Singh I. Normal phospholipid-related signal transduction in autism. Prog Neuropsychopharmacol Biol Psychiatry. 12. 2002;26(7–8):1405-7. X-4. [pmid: 12502030].
2740 Quill K, Gurry S, Larkin A. Daily life therapy: a Japanese model for educating children with autism. J Autism Dev Disord. 12. 1989;19(4):625-35. X-1, X-2, X-4, X-10. [pmid: 2606888].
2741 Quilty KM. Teaching Paraprofessionals How to Write and Implement Social Stories for Students With Autism Spectrum Disorders. Remedial and Special Education. 05–06. 2007;28(3):182-189. X-3, X-4.
2742 Quintana H, Birmaher B, Stedge D, et al. Use of methylphenidate in the treatment of children with autistic disorder. J Autism Dev Disord. 06. 1995;25(3):283-94. X-10. [pmid: 7559293].
2743 Quirantes D. Collaborative approach to autism: a parent’s perspective. J Spec Pediatr Nurs. 07. 2009;14(3):203-5. X-1, X-2, X-3, X-4. [pmid: 19614830].
2744 Raffaele L, Settineri N, Pergolizzi S, et al. Wedge factor changes with depth and field size on a linear accelerator with a motorized wedge. Radiol Med. 09. 1995;90(3):304-6. X-1, X-3, X-4, X-10. [pmid: 7501838].
2745 Raglio A, Traficante D, Oasi O. A coding scheme for the evaluation of the relationship in music therapy sessions. Psychol Rep. 08. 2006;99(1):85-90. X-3, X-4. [pmid: 17037452].
2746 Raheja S, Libretto SE, Singh I. Successful use of risperidone in an adult with the Pervasive Developmental Disorder, Asperger’s syndrome: A case report. British Journal of Developmental Disabilities. 01. 2002;48(94,Pt1):61-66. X-1, X-3.
2747 Raiten DJ, Massaro T. Perspectives on the nutritional ecology of autistic children. J Autism Dev Disord. 06. 1986;16(2):133-43. X-4, X-10. [pmid: 3722115].
2748 Rajendran G, Mitchell P, Rickards H. How do individuals with Asperger syndrome respond to nonliteral language and inappropriate requests in computer-mediated communication?. J Autism Dev Disord. 08. 2005;35(4):429-43. X-4. [pmid: 16134029].
2749 Ramachandran VS, Oberman LM. Broken mirrors: a theory of autism. Sci Am. 11. 2006;295(5):62-9. X-1, X-2, X-3, X-4.
2750 Ramaekers VT, Blau N, Sequeira JM, et al. Folate receptor autoimmunity and cerebral folate deficiency in low-functioning autism with neurological deficits. Neuropediatrics. 12. 2007;38(6):276-81. X-3. [pmid: 18461502].
2751 Ramos AE, Shytle RD, Silver AA, et al. Ziprasidone-Induced Oculogyric Crisis. Journal of the American Academy of Child & Adolescent Psychiatry. 09. 2003;42(9):1013-1014. X-3. [pmid: 12964566].
2752 Randell T, Hall M, Bizo L, et al. DTkid: interactive simulation software for training tutors of children with autism. J Autism Dev Disord. 04. 2007;37(4):637-47. X-1, X-4. [pmid: 17019627].
2753 Randi J, Newman T, Grigorenko EL. Teaching Children with Autism to Read for Meaning: Challenges and Possibilities. J Autism Dev Disord. 2010. 01. 26. X-1, X-2, X-3, X-4.
2754 Rao PA, Beidel DC. The Impact of Children with High-Functioning Autism on Parental Stress, Sibling Adjustment, and Family Functioning. Behavior Modification. 2009;33(4):437-451. X-1, X-4. [pmid: 19436073].
2755 Rao PA, Beidel DC, Murray MJ. Social Skills Interventions for Children with Asperger’s Syndrome or High-Functioning Autism: A Review and Recommendations. Journal of Autism and Developmental Disorders. 02. 2008;38(2):353-361. X-1, X-2, X-3, X-4. [pmid: 17641962].
2756 Rapin I. Children with inadequate language development: management guidelines for otolaryngologists. Int J Pediatr Otorhinolaryngol. 12. 1988;16(3):189-98. X-1, X-2, X-3, X-4, X-10. [pmid: 3235285].
2757 Raposa KA. Behavioral management for patients with intellectual and developmental disorders. Dent Clin North Am. 04. 2009;53(2):359-73. xi. X-1, X-2, X-3, X-4. [pmid: 19269404].
2758 Rapp JT. Toward an empirical method for identifying matched stimulation for automatically reinforced behavior: A preliminary investigation. Journal of Applied Behavior Analysis. Spr. 2006;39(1):137-140. X-3. [pmid: 16602394].
2759 Rapp JT. Further evaluation of methods to identify matched stimulation. J Appl Behav Anal. Spring. 2007;40(1):73-88. X-3. [pmid: 17471794].
2760 Rapp JT, Dozier CL, Carr JE. Functional assessment and treatment of pica: A single-case experiment. Behavioral Interventions. 04–06. 2001;16(2):111-125. X-3.
2761 Rapp JT, Dozier CL, Carr JE, et al. Functional analysis of hair manipulation: A replication and extension. Behavioral Interventions. 04–06. 2000;15(2):121-133. X-3.
2762 Rapp JT, Vollmer, Timothy R. Stereotypy II: A Review of Neurobiological Interpretations and Suggestions for an Integration with Behavioral Methods. Research in Developmental Disabilities: A Multidisciplinary Journal. 11–12. 2005;26(6):548-564. X-1, X-2, X-3, X-4.
2763 Rapp JT, Vollmer TR, Hovanetz AN. Evaluation and Treatment of Swimming Pool Avoidance Exhibited by an Adolescent Girl With Autism. Behavior Therapy. Win. 2005;36(1):101-105. X-1, X-3.
2764 Rapp JT, Vollmer TR, St Peter C, et al. Analysis of response allocation in individuals with multiple forms of stereotyped behavior. Journal of Applied Behavior Analysis. Win. 2004;37(4):481-501. X-3. [pmid: 15669407].
2765 Rapport MD. Bridging theory and practice: conceptual understanding of treatments for children with attention deficit hyperactivity disorder (ADHD), obsessive-compulsive disorder (OCD), autism, and depression. J Clin Child Psychol. 03. 2001;30(1):3-7. X-2, X-4. [pmid: 11294075].
2766 Rasalam AD, Hailey H, Williams JH, et al. Characteristics of fetal anticonvulsant syndrome associated autistic disorder. Dev Med Child Neurol. 08. 2005;47(8):551-5. X-4. [pmid: 16108456].
2767 Rastam M, Bjure J, Vestergren E, et al. Regional cerebral blood flow in weight-restored anorexia nervosa: a preliminary study. Dev Med Child Neurol. 04. 2001;43(4):239-42. X-1, X-4. [pmid: 11305400].
2768 Rastam M, Gillberg C, Wentz E. Outcome of teenage-onset anorexia nervosa in a Swedish community-based sample. Eur Child Adolesc Psychiatry. 2003;12(Suppl 1):I78-90. X-1, X-4. [pmid: 12567219].
2769 Ratey JJ, Bemporad JR, Sorgi P, et al. Open trial effects of beta-blockers on speech and social behaviors in 8 autistic adults. Journal of Autism and Developmental Disorders. 09. 1987;17(3):439-446. X-1, X-3, X-10. [pmid: 3654495].
2770 Ratliff-Schaub K, Carey T, Reeves GD, et al. Randomized controlled trial of transdermal secretin on behavior of children with autism. Autism. 07. 2005;9(3):256-65. X-3. [pmid: 15937041].
2771 Rausch JL, Johnson ME, Fei YJ, et al. Initial conditions of serotonin transporter kinetics and genotype: influence on SSRI treatment trial outcome. Biol Psychiatry. 05. 1. 2002;51(9):723-32. X-1, X-4. [pmid: 11983186].
2772 Rausch JL, Sirota EL, Londino DL, et al. Open-label risperidone for Asperger’s disorder: negative symptom spectrum response. J Clin Psychiatry. 12. 2005;66(12):1592-7. X-1. [pmid: 16401163].
2773 Ravizza SM, Ivry RB. Comparison of the basal ganglia and cerebellum in shifting attention. J Cogn Neurosci. 04. 1. 2001;13(3):285-97. X-1, X-3, X-4. [pmid: 11371307].
2774 Ray ER, Chatterton K, Thomas K, et al. Hexylaminolevulinate photodynamic diagnosis for multifocal recurrent nonmuscle invasive bladder cancer. J Endourol. 06. 2009;23(6):983-8. X-1, X-3, X-4. [pmid: 19441882].
2775 Ray F, Marks C, Bray-Garretson H. Challenges to Treating Adolescents with Asperger’s Syndrome Who are Sexually Abusive. Sexual Addiction & Compulsivity. 12. 2004;11(4):265-285. X-1, X-2, X-4.
2776 Ray KP, Skinner CH, Watson TS. Transferring stimulus control via momentum to increase compliance in a student with autism: A demonstration of collaborative consultation. School Psychology Review. 1999;28(4):622-628. X-10.
2777 Ray T, Tobias JD. Dexmedetomidine for sedation during electroencephalographic analysis in children with autism, pervasive developmental disorders, and seizure disorders. J Clin Anesth. 08. 2008;20(5):364-8. X-4. [pmid: 18761245].
2778 Ray TC, King LJ, Grandin T. The effectiveness of self-initiated vestibular stimulation in producing speech sounds in an autistic child. Occupational Therapy Journal of Research. 05–06. 1988;8(3):186-190. X-3, X-10.
2779 Rayner C, Denholm C, Sigafoos J. Video-Based Intervention for Individuals with Autism: Key Questions that Remain Unanswered. Research in Autism Spectrum Disorders. 04–06. 2009;3(2):291-303. X-1, X-2, X-3, X-4.
2780 Raz N, Pritchard WS, August GJ. Effects of fenfluramine on EEG and brainstem average evoked response in infantile autism. Preliminary investigation. Neuropsychobiology. 1987;18(2):105-9. X-10. [pmid: 2836758].
2781 Read SG, Rendall M. An Open-Label Study of Risperidone in the Improvement of Quality of Life and Treatment of Symptoms of Violent and Self-Injurious Behaviour in Adults with Intellectual Disability. Journal of Applied Research in Intellectual Disabilities. 05. 2007;20(3):256-264. X-1.
2782 Reagon KA, Higbee TS. Parent-Implemented Script Fading to Promote Play-Based Verbal Initiations in Children with Autism. Journal of Applied Behavior Analysis. Fall. 2009;42(3):659-664. X-1, X-3. [pmid: 20190925].
2783 Reagon KA, Higbee TS, Endicott K. Teaching Pretend Play Skills to a Student with Autism Using Video Modeling with a Sibling as Model and Play Partner. Education & Treatment of Children. 08. 2006;29(3):517-528. X-3.
2784 Realmuto GM, August GJ, Garfinkel BD. Clinical effect of buspirone in autistic children. Journal of Clinical Psychopharmacology. 04. 1989;9(2):122-125. X-3, X-10. [pmid: 2723129].
2785 Realmuto GM, Ruble LA. Sexual behaviors in autism: Problems of definition and management. Journal of Autism and Developmental Disorders. 04. 1999;29(2):121-127. X-1, X-3, X-10. [pmid: 10382132].
2786 Reaven J, Hepburn S. Cognitive-behavioral treatment of obsessive-compulsive disorder in a child with Asperger syndrome: a case report. Autism. 06. 2003;7(2):145-64. X-3. [pmid: 12846384].
2787 Redefer LA, Goodman JF. Brief report: pet-facilitated therapy with autistic children. J Autism Dev Disord. 09. 1989;19(3):461-7. X-10. [pmid: 2793790].
2788 Redefer LA, Goodman JF. Pet-facilitated therapy with autistic children. Journal of Autism and Developmental Disorders. 09. 1989;19(3):461-467. X-10. [pmid: 2793790].
2789 Redfearn J. Possible psychosomatic hazards to the therapist: patients as self-objects. J Anal Psychol. 04. 2000;45(2):177-94. X-1, X-2, X-4. [pmid: 14533393].
2790 Redl F. Rethinking Youthful Defiance. Reclaiming Children and Youth: The Journal of Strength-based Interventions. Spr. 2007;16(1):33-35. X-1, X-2, X-3, X-4.
2791 Reed CL, Beall PM, Stone VE, et al. Brief Report: Perception of Body Posture--What Individuals with Autism Spectrum Disorder Might Be Missing. Journal of Autism and Developmental Disorders. 09. 2007;37(8):1576-1584. X-1, X-4. [pmid: 17029019].
2792 Reed P, Broomfield L, McHugh L, et al. Extinction of Over-Selected Stimuli Causes Emergence of Under-Selected Cues in Higher-Functioning Children with Autistic Spectrum Disorders. Journal of Autism and Developmental Disorders. 02. 2009;39(2):290-298. X-4. [pmid: 18787937].
2793 Reese RM, Richman DM, Zarcone J, et al. Individualizing functional assessments for children with autism: The contribution of perseverative behavior and sensory disturbances to disruptive behavior. Focus on Autism and Other Developmental Disabilities. Sum. 2003;18(2):89-94. X-4.
2794 Reese RM, Sherman JA, Sheldon JB. Reducing disruptive behavior of a group-home resident with autism and mental retardation. Journal of Autism and Developmental Disorders. 04. 1998;28(2):159-165. X-1, X-3, X-10. [pmid: 9586778].
2795 Reeve CE, Carr EG. Prevention of severe behavior problems in children with developmental disorders. Journal of Positive Behavior Interventions. Sum. 2000;2(3):144-160. X-3.
2796 Reeve SA, Reeve KF, Townsend DB, et al. Establishing a generalized repertoire of helping behavior in children with autism. J Appl Behav Anal. Spring. 2007;40(1):123-36. X-3. [pmid: 17471797].
2797 Reeves C. Children, words and symptomatic acts. Journal of Child Psychotherapy. 08. 1996;22(2):279-298. X-3, X-4, X-10.
2798 Regal RA, Rooney JR, Wandas T. Facilitated communication: an experimental evaluation. J Autism Dev Disord. 06. 1994;24(3):345-55. X-10. [pmid: 8050987].
2799 Regine WF, Abrams RA. Adjuvant therapy for pancreatic cancer: back to the future. Int J Radiat Oncol Biol Phys. 08. 1. 1998;42(1):59-63. X-1, X-2, X-4, X-10. [pmid: 9747820].
2800 Rehfeldt RA, Chambers MR. Functional analysis and treatment of verbal perseverations displayed by an adult with autism. J Appl Behav Anal. Summer. 2003;36(2):259-61. X-1, X-3. [pmid: 12858991].
2801 Rehfeldt RA, Kinney EM, Root S, et al. Creating activity schedules using Microsoft Powerpoint. J Appl Behav Anal. Spring. 2004;37(1):115-28. X-1, X-2, X-3, X-4. [pmid: 15154226].
2802 Rehfeldt RA, Latimore D, Stromer R. Observational learning and the formation of classes of reading skills by individuals with autism and other developmental disabilities. Res Dev Disabil. 09–10. 2003;24(5):333-58. X-1, X-3, X-4. [pmid: 12951131].
2803 Reichelt KL, Knivsberg A-M, Lind G, et al. Probable etiology and possible treatment of childhood autism. Brain Dysfunction. 11–12. 1991;4(6):308-319. X-10.
2804 Reichle J, McComas J, Dahl N, et al. Teaching an Individual with Severe Intellectual Delay to Request Assistance Conditionally. Educational Psychology. 04–06. 2005;25(2–3):275-286. X-1, X-3.
2805 Reichow B, Sabornie EJ. Brief Report: Increasing Verbal Greeting Initiations for a Student with Autism via a Social Story[TM] Intervention. Journal of Autism and Developmental Disorders. 12. 2009;39(12):1740-1743. X-3.
2806 Reichow B, Volkmar FR, Cicchetti DV. Development of the Evaluative Method for Evaluating and Determining Evidence-Based Practices in Autism. Journal of Autism and Developmental Disorders. 08. 2008;38(7):1311-1319. X-1, X-2, X-3, X-4. [pmid: 18095149].
2807 Reichow B, Wolery M. Comprehensive Synthesis of Early Intensive Behavioral Interventions for Young Children with Autism Based on the UCLA Young Autism Project Model. Journal of Autism and Developmental Disorders. 01. 2009;39(1):23-41. X-1, X-2, X-3, X-4. [pmid: 18535894].
2808 Reid DH, Parsons MB, Lattimore LP, et al. Improving staff performance through clinician application of outcome management. Res Dev Disabil. 03–04. 2005;26(2):101-16. X-1, X-3, X-4. [pmid: 15590242].
2809 Reilly C, Nelson DL, Bundy AC. Sensorimotor versus fine motor activities in eliciting vocalizations in autistic children. Occupational Therapy Journal of Research. 10. 1983;3(4):199-212. X-10.
2810 Reiman M, Albers L. International adoption: A four-year-old child with unusual behaviors adopted at six months of age: Website discussion. Journal of Developmental & Behavioral Pediatrics. 02. 2003;24(1):67. X-2, X-3, X-4.
2811 Reinecke DR, Newman B, Kurtz AL, et al. Teaching deception skills in a game-play context to three adolescents with autism. Journal of Autism and Developmental Disorders. 04. 1997;27(2):127-137. X-10. [pmid: 9105964].
2812 Reinhartsen DB, Garfinkle AN, Wolery M. Engagement with Toys in Two-Year-Old Children with Autism: Teacher Selection versus Child Choice. Journal of the Association for Persons with Severe Handicaps Journal Citation. Fall. 2002;27(3):175-87. Publisher:. 2002 Pub Types: Journal Articles; Reports - Research. X-3, X-4.
2813 Reinhold JA, Molloy CA, Manning-Courtney P. Electroencephalogram abnormalities in children with autism spectrum disorders. J Neurosci Nurs. 06. 2005;37(3):136-8. X-4. [pmid: 16001817].
2814 Reinke T. States increasingly mandate special autism services. Insurers are being handed some treatment responsibility for this complex disorder, but some say that it is an educational, not medical, task. Manag Care. 08. 2008;17(8):35-6. 39. X-1, X-2, X-3, X-4.
2815 Reiss AL. Childhood Developmental Disorders: An Academic and Clinical Convergence Point for Psychiatry, Neurology, Psychology and Pediatrics. Journal of Child Psychology and Psychiatry. 01–02. 2009;50(1–2):87-98. X-1, X-2, X-3, X-4. [pmid: 19220592].
2816 Reiss AL, Egel AL, Feinstein C, et al. Effects of fenfluramine on social behavior in autistic children. J Autism Dev Disord. 12. 1988;18(4):617-25. X-3, X-10. [pmid: 3215887].
2817 Reiter S, Vitani T. Inclusion of Pupils with Autism: The Effect of an Intervention Program on the Regular Pupils’ Burnout, Attitudes and Quality of Mediation. Autism: The International Journal of Research and Practice. 2007;11(4):321-333. X-3, X-4. [pmid: 17656397].
2818 Remington B, Clarke S. Acquisition of expressive signing by autistic children: an evaluation of the relative effects of simultaneous communication and sign-alone training. J Appl Behav Anal. Fall. 1983;16(3):315-27. X-3, X-10. [pmid: 6643323].
2819 Remington G, Sloman L, Konstantareas M, et al. Clomipramine versus haloperidol in the treatment of autistic disorder: a double-blind, placebo-controlled, crossover study. J Clin Psychopharmacol. 08. 2001;21(4):440-4. X-1. [pmid: 11476129].
2820 Renty J, Roeyers H. Satisfaction with formal support and education for children with autism spectrum disorder: the voices of the parents. Child Care Health Dev. 05. 2006;32(3):371-85. X-1, X-4. [pmid: 16634981].
2821 Resch RC, Grand S, May M. Eye, hand, and the mother: The mother’s role in the neuromaturation and development of an autistic child. Bulletin of the Menninger Clinic. 07. 1988;52(4):304-320. X-3, X-4, X-10. [pmid: 3401627].
2822 Reynhout G, Carter M. Social Stories[TM] for Children with Disabilities. Journal of Autism and Developmental Disorders. 05. 2006;36(4):445-469. X-1, X-2, X-3, X-4. [pmid: 16755384].
2823 Reynhout G, Carter M. Social Story[Trademark sign] Efficacy with a Child with Autism Spectrum Disorder and Moderate Intellectual Disability. Focus on Autism and Other Developmental Disabilities. Fall. 2007;22(3):173-182. X-3.
2824 Reynhout G, Carter M. A Pilot Study to Determine the Efficacy of a Social Story [TM] Intervention for a Child with Autistic Disorder, Intellectual Disability and Limited Language Skills. Australasian Journal of Special Education. 09. 2008;32(2):161-175. X-1, X-3.
2825 Reynhout G, Carter M. The Use of Social Stories by Teachers and Their Perceived Efficacy. Research in Autism Spectrum Disorders. 01. 2009;3(1):232-251. X-4.
2826 Rhine D, Tarbox J. Chewing gum as a treatment for rumination in a child with autism. Journal of Applied Behavior Analysis. Sum. 2009;42(2):381-385. X-3. [pmid: 19949528].
2827 Rhoades RA, Scarpa A, Salley B. The importance of physician knowledge of autism spectrum disorder: results of a parent survey. BMC Pediatr. 2007;7:37. X-1, X-2, X-3, X-4. [pmid: 18021459].
2828 Rhode M. Autistic breathing. Journal of Child Psychotherapy. Special Issue: Autism. 04. 1994;20(1):25-41. X-3, X-10.
2829 Rhode M. Links between Henri Rey’s thinking and psychoanalytic work with autistic children. Psychoanalytic Psychotherapy. 1995;9(2):149-155. X-1, X-2, X-3, X-4, X-10.
2830 Rhode M. Some aspects of dependence on the therapist’s mental functioning. Journal of Melanie Klein & Object Relations. 06. 1998;16(2):233-243. X-3, X-4, X-10.
2831 Rhode M. Different responses to trauma in two children with autistic spectrum disorder: the mouth as crossroads for the sense of self. Journal of Child Psychotherapy. 04. 2004;30(1):3-20. X-3.
2832 Riby DM, Doherty-Sneddon G, Bruce V. Exploring face perception in disorders of development: evidence from Williams syndrome and autism. J Neuropsychol. 03. 2008;2(Pt 1):47-64. X-4. [pmid: 19334304].
2833 Ricciardi JN. Achieving human service outcomes through competency-based training: a guide for managers. Behav Modif. 05. 2005;29(3):488-507. X-1, X-2, X-3, X-4. [pmid: 15784751].
2834 Ricciardi JN, Luiselli JK. Behavioral intervention to eliminate socially mediated urinary incontinence in a child with autism. Child & Family Behavior Therapy. 2003;25(4):53-63. X-3.
2835 Ricciardi JN, Luiselli JK, Camare M. Shaping approach responses as intervention for specific phobia in a child with autism. Journal of Applied Behavior Analysis. Win. 2006;39(4):445-448. X-3. [pmid: 17236342].
2836 Ricciardi JN, Luiselli JK, Terrill S, et al. Alternative response training with contingent practice as intervention for pica in a school setting. Behavioral Interventions. 07. 2003;18(3):219-226. X-3.
2837 Rice MA, Haas RH. The nutritional aspects of Rett syndrome. J Child Neurol. 1988;3(Suppl):S35-42. X-1, X-4, X-10. [pmid: 3198901].
2838 Richdale AL. Sleep problems in autism: prevalence, cause, and intervention. Dev Med Child Neurol. 01. 1999;41(1):60-6. X-10. [pmid: 10068053].
2839 Richler J, Huerta M, Bishop SL, et al. Developmental trajectories of restricted and repetitive behaviors and interests in children with autism spectrum disorders. Dev Psychopathol. Winter. 2010;22(1):55-69. X-4. [pmid: 20102647].
2840 Richman DM, Reese RM, Daniels D. Use of evidence-based practice as a method for evaluating the effects of secretin on a child with autism. Focus on Autism and Other Developmental Disabilities. Win. 1999;14(4):204-211. X-3, X-10.
2841 Richman DM, Wacker DP, Asmus JM, et al. Functional analysis and extinction of different behavior problems exhibited by the same individual. Journal of Applied Behavior Analysis. Fal. 1998;31(3):475-478. X-1, X-3, X-10. [pmid: 9757585].
2842 Richman DM, Wacker DP, Winborn L. Response efficiency during functional communication training: Effects of effort on response allocation. Journal of Applied Behavior Analysis. Spr. 2001;34(1):73-76. X-3. [pmid: 11317991].
2843 Ridley J, Hunter S. The development of supported employment in Scotland. Journal of Vocational Rehabilitation. Special Issue: Spinal Cord Injury and Vocational Rehabilitation. 2006;25(1):57-68. X-1, X-2, X-3, X-4.
2844 Riedlinger JE. The scheduling of MDMA: a pharmacist’s perspective. J Psychoactive Drugs. 07–09. 1985;17(3):167-71. X-1, X-2, X-3, X-4, X-10. [pmid: 2865343].
2845 Rimland B. Controversies in the treatment of autistic children: Vitamin and drug therapy. Journal of Child Neurology. 1988;3(Suppl):68-72. X-1, X-2, X-3, X-4, X-10.
2846 Rimland B, Edelson SM. Brief report: a pilot study of auditory integration training in autism. J Autism Dev Disord. 02. 1995;25(1):61-70. X-10. [pmid: 7608035].
2847 Rincover A, Newsom CD. The relative motivational properties of sensory and edible reinforcers in teaching autistic children. Journal of Applied Behavior Analysis. Fal. 1985;18(3):237-248. X-10. [pmid: 4044457].
2848 Ring HA, Baron-Cohen S, Wheelwright S, et al. Cerebral correlates of preserved cognitive skills in autism: A functional MRI study of Embedded Figures Task performance. Brain: A Journal of Neurology. 07. 1999;122(7):1305-1315. X-3, X-4, X-10. [pmid: 10388796].
2849 Ringdahl JE, Kitsukawa K, Andelman MS, et al. Differential reinforcement with and without instructional fading. Journal of Applied Behavior Analysis. Fal. 2002;35(3):291-294. X-3. [pmid: 12365743].
2850 Ritvo ER, Freeman BJ. A medical model of autism: etiology, pathology and treatment. Pediatr Ann. 04. 1984;13(4):298-305. X-1, X-2, X-3, X-4, X-10. [pmid: 6610163].
2851 Ritvo ER, Freeman BJ, Geller E, et al. Effects of fenfluramine on 14 outpatients with the syndrome of autism. J Am Acad Child Psychiatry. 11. 1983;22(6):549-58. X-10. [pmid: 6655169].
2852 Ritvo ER, Freeman BJ, Yuwiler A, et al. Fenfluramine treatment of autism: UCLA collaborative study of 81 patients at nine medical centers. Psychopharmacol Bull. 1986;22(1):133-40. X-10. [pmid: 3726059].
2853 Ritvo ER, Freeman BJ, Yuwiler A, et al. Study of fenfluramine in outpatients with the syndrome of autism. J Pediatr. 11. 1984;105(5):823-8. X-10. [pmid: 6502317].
2854 Ritvo ER, Neathery SK. Parental reports on favorable responses to fenfluramine treatment in autism. Brain Dysfunction. 11–12. 1990;3(5–6):308-314. X-10.

## Medical

2855 Riva D, Giorgi C. The cerebellum contributes to higher functions during development: evidence from a series of children surgically treated for posterior fossa tumours. Brain. 05. 2000;123(Pt 5):1051-61. X-1, X-4. [pmid: 10775549].
2856 Roane HS, Fisher WW, Sgro GM, et al. An alternative method of thinning reinforcer delivery during differential reinforcement. Journal of Applied Behavior Analysis. Sum. 2004;37(2):213-218. X-3. [pmid: 15293640].
2857 Robbins FR, Dunlap G. Effects of task difficulty on parent teaching skills and behavior problems of young children with autism. Am J Ment Retard. 05. 1992;96(6):631-43. X-10. [pmid: 1344940].
2858 Robbins FR, Dunlap G, Plienis AJ. Family characteristics, family training, and the progress of young children with autism. Journal of Early Intervention. Spr. 1991;15(2):173-184. X-10.
2859 Roberts JE, Mankowski JB, Sideris J, et al. Trajectories and predictors of the development of very young boys with fragile X syndrome. J Pediatr Psychol. 09. 2009;34(8):827-36. X-1, X-3, X-4. [pmid: 19074489].
2860 Roberts JMA, Keane E, Clark TR. Making Inclusion Work: Autism Spectrum Australia Satellite Class Project. TEACHING Exceptional Children. 11–12. 2008;41(2):22-27. X-1, X-2, X-3, X-4.
2861 Roberts RN. Wow! Models of Service Coordination Do Make a Difference. Journal of Early Intervention. 2006;28(3):169-171. X-1, X-2, X-3, X-4.
2862 Roberts V, Joiner R. Investigating the Efficacy of Concept Mapping with Pupils with Autistic Spectrum Disorder. British Journal of Special Education. 09. 2007;34(3):127-135. X-3.
2863 Roberts-Gwinn MM, Luiten L, Derby KM, et al. Identification of competing reinforcers for behavior maintained by automatic reinforcement. Journal of Positive Behavior Interventions. Spr. 2001;3(2):83-87. X-3.
2864 Robertson K, Chamberlain B, Kasari C. General education teachers’ relationships with d students with autism. J Autism Dev Disord. 04. 2003;33(2):123-30. X-4. [pmid: 12757351].
2865 Roberts-Pennell D, Sigafoos J. Teaching young children with developmental disabilities to request more play using the behaviour chain interruption strategy. Journal of Applied Research in Intellectual Disabilities. 1999;12(2):100-112. X-10.
2866 Robins B, Dickerson P, Stribling P, et al. Robot-mediated joint attention in children with autism: A case study in robot-human interaction. Interaction Studies: Social Behaviour and Communication in Biological and Artificial Systems. 2004;5(2):161-198. X-3.
2867 Robins DL. Screening for autism spectrum disorders in primary care settings. Autism. Special Issue: Early detection. 09. 2008;12(5):537-556. X-4.
2868 Robinson TW. Homeopathic Secretin in autism: a clinical pilot study. Br Homeopath J. 04. 2001;90(2):86-91. X-1, X-3, X-4. [pmid: 11341462].
2869 Rocha ML, Schreibman L, Stahmer AC. Effectiveness of Training Parents to Teach Joint Attention in Children with Autism. Journal of Early Intervention. 2007;29(2):154-173. X-3.
2870 Rochester L, Burn DJ, Woods G, et al. Does auditory rhythmical cueing improve gait in people with Parkinson’s disease and cognitive impairment? A feasibility study. Mov Disord. 04. 30. 2009;24(6):839-45. X-1, X-2, X-3, X-4. [pmid: 19199354].
2871 Rodger S, Braithwaite M, Keen D. Early Intervention for Children with Autism: Parental Priorities. Australian Journal of Early Childhood. 09. 2004;29(3):34-41. X-6.
2872 Rodger S, Keen D, Braithwaite M, et al. Mothers’ Satisfaction with a Home Based Early Intervention Programme for Children with ASD. Journal of Applied Research in Intellectual Disabilities. 03. 2008;21(2):174-182. X-1, X-3, X-4.
2873 Rodrigue JR, Morgan SB, Geffken GR. A comparative evaluation of adaptive behavior in children and adolescents with autism, Down syndrome, and normal development. J Autism Dev Disord. 06. 1991;21(2):187-96. X-4, X-10. [pmid: 1830878].
2874 Roeyers H. The influence of nonhandicapped peers on the social interactions of children with a pervasive development disorder. J Autism Dev Disord. 06. 1996;26(3):303-20. X-10. [pmid: 8792262].
2875 Rogers EJ. Has enhanced folate status during pregnancy altered natural selection and possibly Autism prevalence? A closer look at a possible link. Med Hypotheses. 09. 2008;71(3):406-10. X-1, X-2, X-3, X-4. [pmid: 18514430].
2876 Rogers SJ. Empirically supported comprehensive treatments for young children with autism. Journal of Clinical Child Psychology. Special Issue: Empirically supported psychosocial interventions for children. 06. 1998;27(2):168-179. X-1, X-2, X-3, X-4, X-10.
2877 Rogers SJ. Interventions that facilitate socialization in children with autism. J Autism Dev Disord. 10. 2000;30(5):399-409. X-1, X-2, X-3. [pmid: 11098875].
2878 Rogers SJ, Bennetto L, McEvoy R, et al. Imitation and pantomime in high-functioning adolescents with autism spectrum disorders. Child Development. 10. 1996;67(5):2060-2073. X-10. [pmid: 9022229].
2879 Rogers SJ, DiLalla DL. A comparative study of the effects of a developmentally based instructional model on young children with autism and young children with other disorders of behavior and development. Topics in Early Childhood Special Education. Sum. 1991;11(2):29-47. X-10.
2880 Rogers SJ, Hayden D, Hepburn S, et al. Teaching young nonverbal children with autism useful speech: a pilot study of the Denver Model and PROMPT interventions. J Autism Dev Disord. 11. 2006;36(8):1007-24. X-6. [pmid: 16845576].
2881 Rogers SJ, Hepburn SL, Stackhouse T, et al. Imitation performance in toddlers with autism and those with other developmental disorders. J Child Psychol Psychiatry. 07. 2003;44(5):763-81. X-4. [pmid: 12831120].
2882 Rogers SJ, Lewis H. An effective day treatment model for young children with pervasive developmental disorders. J Am Acad Child Adolesc Psychiatry. 03. 1989;28(2):207-14. X-10. [pmid: 2466824].
2883 Rogers SJ, Vismara LA. Evidence-Based Comprehensive Treatments for Early Autism. Journal of Clinical Child and Adolescent Psychology. 01. 2008;37(1):8-38. X-1, X-2, X-3, X-4. [pmid: 18444052].
2884 Rogers SJ, Young GS, Cook I, et al. Imitating actions on objects in early-onset and regressive autism: Effects and implications of task characteristics on performance. Dev Psychopathol. Winter. 2010;22(1):71-85. X-4. [pmid: 20102648].
2885 Rojahn J, McGonigle JJ, Curcio C, et al. Suppression of pica by water mist and aromatic ammonia: A comparative analysis. Behavior Modification. 01. 1987;11(1):65-74. X-1, X-3, X-10. [pmid: 3508376].
2886 Roll-Pettersson L, Ala’i-Rosales S. Using blended and guided technologies in a university course for scientist-practitioners: teaching applied behaviour analysis to autism professionals. J Intellect Disabil. 06. 2009;13(2):113-42. X-1, X-3, X-4. [pmid: 19628533].
2887 Romanczyk RG. Micro-computers and behavior therapy: A powerful alliance. the Behavior Therapist. 04. 1984;7(4):59-64. X-4, X-10.
2888 Romaniuk C, Miltenberger R, Conyers C, et al. The influence of activity choice on problem behaviors maintained by escape versus attention. Journal of Applied Behavior Analysis. Win. 2002;35(4):349-362. X-3. [pmid: 12555907].
2889 Romano JP, Roll D. Expanding the utility of behavioral momentum for youth with developmental disabilities. Behavioral Interventions. 04–06. 2000;15(2):99-111. X-1, X-3, X-4.
2890 Ronder RW, Kastner T, Parker SJ, et al. Serving people with developmental disabilities in Medicaid managed care. Manag Care Q. Spring. 1999;7(2):23-30. X-1, X-2, X-3, X-4, X-10. [pmid: 10537636].
2891 Roscoe EM, Carreau A, MacDonald J, et al. Further Evaluation of Leisure Items in the Attention Condition of Functional Analyses. Journal of Applied Behavior Analysis. Fall. 2008;41(3):351-364. X-3, X-4. [pmid: 18816974].
2892 Rose M, Torgerson NG. A behavioral approach to vision and autism. Journal of Optometric Vision Development. Win. 1994;25(4):269-275. X-3, X-4, X-10.
2893 Rose R, Anketell C. The benefits of social skills groups for young people with autism spectrum disorder: A pilot study. Child Care in Practice. 04. 2009;15(2):127-144. X-4.
2894 Rosen CE. Treatment foster home care for autistic children. Child & Youth Services. 1989;12(1–2):121-132. X-10.
2895 Rosenn DW. What is Asperger’s disorder?. Harv Ment Health Lett. 10. 1999;16(4):8. X-10.
2896 Rosenthal-Malek A, Mitchell S. Brief report: the effects of exercise on the self-stimulatory behaviors and positive responding of adolescents with autism. J Autism Dev Disord. 04. 1997;27(2):193-202. X-1, X-10. [pmid: 9105970].
2897 Rosenwasser B, Axelrod S. The contribution of applied behavior analysis to the education of people with autism. Behav Modif. 10. 2001;25(5):671-7. X-1, X-2, X-3, X-4. [pmid: 11642227].
2898 Rosenwasser B, Axelrod S. More contributions of applied behavior analysis to education of people with autism. Behav Modif. 01. 2002;26(1):3-8. X-1, X-2, X-3, X-4. [pmid: 11799653].
2899 Roser K, Mishne J. Beginning treatment of an autistic child from an intersubjective perspective. Psychoanalytic Review. 06. 1996;83(3):343-362. X-3, X-4, X-10. [pmid: 8853207].
2900 Ross C, Davies P, Whitehouse W. Melatonin treatment for sleep disorders in children with neurodevelopmental disorders: an observational study. Dev Med Child Neurol. 05. 2002;44(5):339-44. X-1, X-3, X-4. [pmid: 12033720].
2901 Ross DE. Replacing Faulty Conversational Exchanges for Children with Autism by Establishing a Functionally Equivalent Alternative Response. Education and Training in Mental Retardation and Developmental Disabilities Journal Citation. 12. 2002;37(4):343-62. Publisher:. 2002 Pub Types: Journal Articles; Reports - Research. X-3.
2902 Ross DE, Greer RD. Generalized imitation and the mand: inducing first instances of speech in young children with autism. Res Dev Disabil. 01–02. 2003;24(1):58-74. X-3. [pmid: 12553968].
2903 Ross DL, Klykylo WM, Hitzemann R. Reduction of elevated CSF beta-endorphin by fenfluramine in infantile autism. Pediatr Neurol. 03–04. 1987;3(2):83-6. X-3, X-10. [pmid: 2977280].
2904 Ross RK. Beyond Autism Treatment: The Application of Applied Behavior Analysis in the Treatment of Emotional and Psychological Disorders. International Journal of Behavioral Consultation and Therapy. 2007;3(4):528-536. X-1, X-2, X-3, X-4.
2905 Rossi EL, Rossi KL. The neuroscience of observing consciousness & mirror neurons in therapeutic hypnosis. Am J Clin Hypn. 04. 2006;48(4):263-78. X-1, X-2, X-3, X-4. [pmid: 16696558].
2906 Rossi PG, Posar A, Parmeggiani A, et al. Niaprazine in the treatment of autistic disorder. J Child Neurol. 08. 1999;14(8):547-50. X-10. [pmid: 10456769].
2907 Rossignol DA. Hyperbaric oxygen therapy might improve certain pathophysiological findings in autism. Med Hypotheses. 2007;68(6):1208-27. X-1, X-2, X-3, X-4. [pmid: 17141962].
2908 Rossignol DA. Novel and emerging treatments for autism spectrum disorders: a systematic review. Ann Clin Psychiatry. 10–12. 2009;21(4):213-36. X-1, X-2, X-3, X-4. [pmid: 19917212].
2909 Rossignol DA, Rossignol LW. Hyperbaric oxygen therapy may improve symptoms in autistic children. Med Hypotheses. 2006;67(2):216-28. X-1, X-2, X-3. [pmid: 16554123].
2910 Rossignol DA, Rossignol LW, James SJ, et al. The effects of hyperbaric oxygen therapy on oxidative stress, inflammation, and symptoms in children with autism: an open-label pilot study. BMC Pediatr. 2007;7:36. X-3. [pmid: 18005455].
2911 Rotholz DA, Luce SC. Alternative reinforcement strategies for the reduction of self-stimulatory behavior in autistic youth. Education & Treatment of Children. Fal. 1983;6(4):363-377. X-3, X-10.
2912 Rotman A. Blood platelets in psychopharmacological research. Prog Neuropsychopharmacol Biol Psychiatry. 1983;7(2–3):135-51. X-1, X-3, X-4, X-10. [pmid: 6310688].
2913 Rotman A, Caplan R, Szekely GA. Platelet uptake of serotonin in psychotic children. Psychopharmacology (Berl). 1980;67(3):245-8. X-4, X-10. [pmid: 6770403].
2914 Rousseau MK, Krantz PJ, Poulson CL, et al. Sentence combining as a technique for increasing adjective use in writing by students with autism. Res Dev Disabil. 01–02. 1994;15(1):19-37. X-1, X-3, X-10. [pmid: 8190970].
2915 Rowan E, McKeith IG, Saxby BK, et al. Effects of donepezil on central processing speed and attentional measures in Parkinson’s disease with dementia and dementia with Lewy bodies. Dement Geriatr Cogn Disord. 2007;23(3):161-7. X-1, X-2, X-4. [pmid: 17192712].
2916 Roy H, Gillett T. E-mail: a new technique for forming a therapeutic alliance with high-risk young people failing to engage with mental health services? A case study. Clin Child Psychol Psychiatry. 01. 2008;13(1):95-103. X-1, X-3, X-4. [pmid: 18411868].
2917 Roy M, Dillo W, Bessling S, et al. Effective Methylphenidate Treatment of an Adult Aspergers Syndrome and a Comorbid ADHD: A Clinical Investigation with fMRI. Journal of Attention Disorders. 2009;12(4):381-385. X-1, X-3. [pmid: 19095892].
2918 Rozelle D. “Wheel inside, a real moveable color”, an autistic boy’s search for self through the use of symbolic imagery. Pratt Institute Creative Arts Therapy Review. 1982;3:1-10. X-3, X-10.
2919 Ruberman L. Psychotherapy of children with pervasive developmental disorders. American Journal of Psychotherapy. 2002;56(2):262-274. X-1, X-2, X-3. [pmid: 12125303].
2920 Rubin DM, Feudtner C, Localio R, et al. State variation in psychotropic medication use by foster care children with autism spectrum disorder. Pediatrics. 08. 2009;124(2):e305-12. X-4.
2921 Ruble L, McDuffie A, King AS, et al. Caregiver responsiveness and social interaction behaviors of young children with autism. Topics in Early Childhood Special Education. 11. 2008;28(3):158-170. X-4.
2922 Ruble L, Willis H, Crabtree VM. Social skills group therapy for autism spectrum disorders. Clinical Case Studies. 08. 2008;7(4):287-300. X-3.
2923 Ruble LA, Heflinger CA, Renfrew JW, et al. Access and service use by children with autism spectrum disorders in Medicaid Managed Care. J Autism Dev Disord. 02. 2005;35(1):3-13. X-4. [pmid: 15796117].
2924 Ruble LA, McGrew JH. Community Services Outcomes for Families and Children with Autism Spectrum Disorders. Research in Autism Spectrum Disorders. 10–12. 2007;1(4):360-372. X-1.
2925 Ruble LA, Robson DM. Individual and environmental determinants of engagement in autism. J Autism Dev Disord. 09. 2007;37(8):1457-68. X-3, X-4. [pmid: 17151800].
2926 Ruedrich SL, Wilkinson L. Atypical unipolar depression in mentally retarded patients: Amoxapine treatment. Journal of Nervous and Mental Disease. 03. 1992;180(3):206-207. X-1, X-3, X-10. [pmid: 1588341].
2927 Rugino TA, Janvier YM. Aripiprazole in children and adolescents: clinical experience. J Child Neurol. 07. 2005;20(7):603-10. X-1, X-3, X-4. [pmid: 16159529].
2928 Rugino TA, Samsock TC. Levetiracem in autistic children: An open-label study. Journal of Developmental & Behavioral Pediatrics. 08. 2002;23(4):225-230. X-3. [pmid: 12177568].
2929 Runco MA, Charlop MH, Schreibman L. The occurrence of autistic children’s self-stimulation as a function of familiar versus unfamiliar stimulus conditions. Journal of Autism and Developmental Disorders. 03. 1986;16(1):31-44. X-10. [pmid: 3957857].
2930 Runco MA, Schreibman L. Parental judgments of behavior therapy efficacy with autistic children: a social validation. J Autism Dev Disord. 09. 1983;13(3):237-48. X-3, X-10. [pmid: 6643371].
2931 Runco MA, Schreibman L. Socially validating behavioral objectives in the treatment of autistic children. J Autism Dev Disord. 03. 1987;17(1):141-7. X-10. [pmid: 3571138].
2932 Runco MA, Schreibman L. Children’s judgments of autism and social validation of behavior therapy efficacy. Behavior Therapy. Fal. 1988;19(4):565-576. X-10.
2933 Russell RL, Bryant FB, Estrada AU. Confirmatory P-technique analyses of therapist discourse: high-versus low-quality child therapy sessions. J Consult Clin Psychol. 12. 1996;64(6):1366-76. X-1, X-4, X-10. [pmid: 8991323].
2934 Russo N, Larson C, Kraus N. Audio-vocal system regulation in children with autism spectrum disorders. Exp Brain Res. 06. 2008;188(1):111-24. X-4. [pmid: 18347784].
2935 Russo N, Nicol T, Trommer B, et al. Brainstem transcription of speech is disrupted in children with autism spectrum disorders. Dev Sci. 07. 2009;12(4):557-67. X-1, X-2, X-3, X-4. [pmid: 19635083].
2936 Russo NM, Skoe E, Trommer B, et al. Deficient brainstem encoding of pitch in children with Autism Spectrum Disorders. Clin Neurophysiol. 08. 2008;119(8):1720-31. X-4. [pmid: 18558508].
2937 Rust J, Smith A. How Should the Effectiveness of Social Stories to Modify the Behaviour of Children on the Autistic Spectrum be Tested?. Autism: The International Journal of Research & Practice. 2006;10(2):125-138. X-1, X-2, X-3, X-4. [pmid: 16613863].
2938 Rutherford MD, Young GS, Hepburn S, et al. A longitudinal study of pretend play in autism. J Autism Dev Disord. 07. 2007;37(6):1024-39. X-4. [pmid: 17146707].
2939 Rutter M, Kreppner J, Croft C, et al. Early adolescent outcomes of institutionally deprived and non-deprived adoptees. III. Quasi-autism. J Child Psychol Psychiatry. 12. 2007;48(12):1200-7. X-1, X-4. [pmid: 18093025].
2940 Ryan CS, Hemmes NS, Sturmey P, et al. Effects of a Brief Staff Training Procedure on Instructors’ Use of Incidental Teaching and Students’ Frequency of Initiation toward Instructors. Research in Autism Spectrum Disorders. 01–03. 2008;2(1):28-45. X-1, X-3, X-4.
2941 Rydell PJ, Mirenda P. Effects of high and low constraint utterances on the production of immediate and delayed echolalia in young children with autism. J Autism Dev Disord. 12. 1994;24(6):719-35. X-4, X-10. [pmid: 7844096].
2942 Sabbagh MA, Taylor M. Neural correlates of theory-of-mind reasoning: an event-related potential study. Psychol Sci. 01. 2000;11(1):46-50. X-1, X-4. [pmid: 11228842].
2943 Saffari M. A loving challenge. Rehab Manag. 11. 2006;19(9):18. 20. X-1, X-2, X-3, X-4.
2944 Safran SP. Why Youngsters with Autistic Spectrum Disorders Remain Underrepresented in Special Education. Remedial and Special Education. 2008;29(2):90-95. X-4.
2945 Sagud M, Hotujac L, Mihaljevic-Peles A, et al. Gender differences in depression. Coll Antropol. 06. 2002;26(1):149-57. X-1, X-2, X-4.
2946 Sahley TL, Panksepp J. Brain opioids and autism: an updated analysis of possible linkages. J Autism Dev Disord. 06. 1987;17(2):201-16. X-1, X-2, X-3, X-4, X-10. [pmid: 3038836].
2947 Sainato DM, Goldstein H, Strain PS. Effects of self-evaluation on preschool children’s use of social interaction strategies with their classmates with autism. J Appl Behav Anal. Spring. 1992;25(1):127-41. X-3, X-10. [pmid: 1582962].
2948 Sainato DM, Strain PS, Lefebvre D, et al. Facilitating transition times with handicapped preschool children: a comparison between peer-mediated and antecedent prompt procedures. J Appl Behav Anal. Fall. 1987;20(3):285-91. X-10. [pmid: 3667478].
2949 Sainato DM, Strain PS, Lefebvre D, et al. Effects of self-evaluation on the independent work skills of preschool children with disabilities. Except Child. 04. 1990;56(6):540-9. X-10. [pmid: 2332024].
2950 Sakka SG, Reinhart K, Wegscheider K, et al. Comparison of cardiac output and circulatory blood volumes by transpulmonary thermo-dye dilution and transcutaneous indocyanine green measurement in critically ill patients. Chest. 02. 2002;121(2):559-65. X-1, X-4. [pmid: 11834672].
2951 Saldana D, Alvarez RM, Lobaton S, et al. Objective and subjective quality of life in adults with autism spectrum disorders in southern Spain. Autism. 05. 2009;13(3):303-16. X-1, X-4. [pmid: 19369390].
2952 Salmon G, Cleave H, Samuel C. Development of multi-agency referral pathways for attention-deficit hyperactivity disorder, developmental coordination disorder and autistic spectrum disorders: reflections on the process and suggestions for new ways of working. Clin Child Psychol Psychiatry. 01. 2006;11(1):63-81. X-1, X-2, X-3, X-4. [pmid: 17087487].
2953 Saloviita T. Dry bed training method in the elimination of bed-wetting in two adults with autism and severe mental retardation. Cognitive Behaviour Therapy. 2002;31(3):135-140. X-1, X-3.
2954 Salt J, Sellars V, Shemilt J, et al. The Scottish Centre for Autism preschool treatment programme. I: A developmental approach to early intervention. Autism. 12. 2001;5(4):362-73. X-1, X-2, X-3, X-4. [pmid: 11777254].
2955 Samms-Vaughan M, Franklyn-Banton L. The Role of Early Childhood Professionals in the Early Identification of Autistic Disorder. International Journal of Early Years Education. 03. 2008;16(1):75-84. X-4.
2956 Sanchez LE, Adams PB, Uysal S, et al. A comparison of live and videotape ratings: clomipramine and haloperidol in autism. Psychopharmacol Bull. 1995;31(2):371-8. X-3, X-10. [pmid: 7491394].
2957 Sanchez LE, Campbell M, Small AM, et al. A pilot study of clomipramine in young autistic children. J Am Acad Child Adolesc Psychiatry. 04. 1996;35(4):537-44. X-3, X-10. [pmid: 8919717].
2958 Sanchez-Nieto B, Sanchez-Doblado F, Terron JA, et al. Lateral scatter correction algorithm for percentage depth dose in a large-field photon beam. Med Dosim. Summer. 1997;22(2):121-5. X-1, X-2, X-3, X-4, X-10. [pmid: 9243466].
2959 Sanchez-Valle E, Posada M, Villaverde-Hueso A, et al. Estimating the Burden of Disease for Autism Spectrum Disorders in Spain in 2003. Journal of Autism and Developmental Disorders. 02. 2008;38(2):288-296. X-4. [pmid: 17546489].
2960 Sandford JJ, Gralton E, Donovan WM. Can deception ever be justified on therapeutic grounds? An ethical case report. Psychiatric Bulletin. 06. 2001;25(6):206-208. X-1, X-2, X-3, X-4.
2961 Sandler A. Placebo effects in developmental disabilities: implications for research and practice. Ment Retard Dev Disabil Res Rev. 2005;11(2):164-70. X-1, X-2, X-3, X-4. [pmid: 15977316].
2962 Sandler AD, Bodfish JW. Placebo effects in autism: lessons from secretin. J Dev Behav Pediatr. 10. 2000;21(5):347-50. X-1, X-2, X-3,X-4. [pmid: 11064962].
2963 Sandler AD, Sutton KA, DeWeese J, et al. Lack of benefit of a single dose of synthetic human secretin in the treatment of autism and pervasive developmental disorder. N Engl J Med. 12. 9. 1999;341(24):1801-6. X-10. [pmid: 10588965].
2964 Sandler RH, Finegold SM, Bolte ER, et al. Short-term benefit from oral vancomycin treatment of regressive-onset autism. Journal of Child Neurology. 07. 2000;15(7):429-435. X-3. [pmid: 10921511].
2965 Sandman CA. Beta-endorphin disregulation in autistic and self-injurious behavior: a neurodevelopmental hypothesis. Synapse. 1988;2(3):193-9. X-3, X-4, X-10. [pmid: 2463689].
2966 Sandman CA, Hetrick W, Talyor D, et al. Uncoupling of proopiomelanocortin (POMC) fragments is related to self-injury. Peptides. 06. 2000;21(6):785-91. X-4. [pmid: 10958998].
2967 Sandt D. Social Stories for Students with Autism in Physical Education. Journal of Physical Education, Recreation & Dance (JOPERD). 08. 2008;79(6):42-45. X-1, X-2, X-3, X-4.
2968 Sansosti FJ, Powell-Smith KA. Using Social Stories to Improve the Social Behavior of Children with Asperger Syndrome. Journal of Positive Behavior Interventions. 2006;8(1):43-57. X-3.
2969 Sansosti FJ, Powell-Smith KA. Using Computer-Presented Social Stories and Video Models to Increase the Social Communication Skills of Children with High-Functioning Autism Spectrum Disorders. Journal of Positive Behavior Interventions. 2008;10(3):162-178. X-3.
2970 Sansosti FJ, Powell-Smith KA, Kincaid D. A Research Synthesis of Social Story Interventions for Children with Autism Spectrum Disorders. Focus on Autism and Other Developmental Disabilities. Win. 2004;19(4):194-204. X-1, X-2, X-3, X-4.
2971 Santarcangelo S, Dyer K. Prosodic aspects of motherese: effects on gaze and responsiveness in developmentally disabled children. J Exp Child Psychol. 12. 1988;46(3):406-18. X-10. [pmid: 3216186].
2972 Santarcangelo S, Dyer K, Luce SC. Generalized reduction of disruptive behavior in unsupervised settings through specific toy training. Journal of the Association for Persons with Severe Handicaps. Spr. 1987;12(1):38-44. X-3, X-10.
2973 Santosh PJ, Baird G. Pharmacotherapy of target symptoms in autistic spectrum disorders. Indian J Pediatr. 05. 2001;68(5):427-31. X-1, X-2, X-3,X-4. [pmid: 11407159].
2974 Santosh PJ, Baird G, Pityaratstian N, et al. Impact of comorbid autism spectrum disorders on stimulant response in children with attention deficit hyperactivity disorder: a retrospective and prospective effectiveness study. Child Care Health Dev. 09. 2006;32(5):575-83. X-1. [pmid: 16919137].
2975 Santosh PJ, Mijovic A. Does pervasive developmental disorder protect children and adolescents against drug and alcohol use?. European Child & Adolescent Psychiatry. 06. 2006;15(4):183-188. X-1, X-4. [pmid: 16604379].
2976 Sarokoff RA, Sturmey P. The effects of behavioral skills training on staff implementation of discrete-trial teaching. J Appl Behav Anal. Winter. 2004;37(4):535-8. X-1, X-3, X-4. [pmid: 15669415].
2977 Sarokoff RA, Sturmey P. The Effects of Instructions, Rehearsal, Modeling, and Feedback on Acquisition and Generalization of Staff Use of Discrete Trial Teaching and Student Correct Responses. Research in Autism Spectrum Disorders. 01–03. 2008;2(1):125-136. X-3.
2978 Sarokoff RA, Taylor BA, Poulson CL. Teaching children with autism to engage in conversational exchanges: Script fading with embedded textual stimuli. Journal of Applied Behavior Analysis. Spr. 2001;34(1):81-84. X-3. [pmid: 11317993].
2979 Sartawi AM. Educational and behavioural characteristics of autistic children in the United Arab Emirates. Int J Rehabil Res. 12. 1999;22(4):337-9. X-10. [pmid: 10669987].
2980 Sasso GM, Reimers TM, Cooper LJ, et al. Use of descriptive and experimental analyses to identify the functional properties of aberrant behavior in school settings. J Appl Behav Anal. Winter. 1992;25(4):809-21. X-3, X-4, X-10. [pmid: 1478904].
2981 Saunders RR, Saunders MD, Brewer A, et al. Reduction of self injury in two adolescents with profound retardation by the establishment of a supported routine. Behavioral Interventions. 04. 1996;11(2):59-86. X-10.
2982 Sautter RA, LeBlanc LA, Gillett JN. Using Free Operant Preference Assessments to Select Toys for Free Play between Children with Autism and Siblings. Research in Autism Spectrum Disorders. 01–03. 2008;2(1):17-27. X-3, X-4.
2983 Saw CL, Olivo M, Wohland T, et al. Effects of N-methyl pyrrolidone on the uptake of hypericin in human bladder carcinoma and co-staining with DAPI investigated by confocal microscopy. Technol Cancer Res Treat. 10. 2007;6(5):383-94. X-1, X-4. [pmid: 17877426].
2984 Sawada M, Negoro H, Iida J, et al. Pervasive developmental disorder with attention deficit hyperactivity disorder-like symptoms and mismatch negativity. Psychiatry Clin Neurosci. 08. 2008;62(4):479-81. X-4. [pmid: 18778448].
2985 Sawyer LM, Luiselli JK, Ricciardi JN, et al. Teaching A Child with Autism to Share Among Peers in an Integrated Preschool Classroom: Acquisition, Maintenance, and Social Validation. Education and Treatment of Children. 02. 2005;28(1):1-10. X-3.
2986 Saxena S, Chawla PL. Childhood psychoses: a brief review. Indian J Pediatr. 03–04. 1984;51(409):217-23. X-10. [pmid: 6209218].
2987 Scahill L. How do I decide whether or not to use medication for my child with autism? Should I try behavior therapy first?. J Autism Dev Disord. 07. 2008;38(6):1197-8. X-1, X-2, X-3, X-4. [pmid: 18463973].
2988 Scahill L, Aman MG, McDougle CJ, et al. Trial design challenges when combining medication and parent training in children with pervasive developmental disorders. J Autism Dev Disord. 05. 2009;39(5):720-9. X-1, X-3, X-4. [pmid: 19096921].
2989 Scahill L, Aman MG, McDougle CJ, et al. A prospective open trial of guanfacine in children with pervasive developmental disorders. J Child Adolesc Psychopharmacol. 10. 2006;16(5):589-98. X-3. [pmid: 17069547].
2990 Scahill L, Jekel JF, Schilling LS. Screening child psychiatric inpatients for communication disorders: a pilot study. Arch Psychiatr Nurs. 02. 1991;5(1):31-7. X-1, X-10. [pmid: 2039279].
2991 Scahill L, Koenig K, Carroll DH, et al. Risperidone approved for the treatment of serious behavioral problems in children with autism. J Child Adolesc Psychiatr Nurs. 08. 2007;20(3):188-90. X-1, X-2, X-3. [pmid: 17688557].
2992 Scahill L, McCracken J, McDougle CJ, et al. Methodological issues in designing a multisite trial of risperidone in children and adolescents with autism. J Child Adolesc Psychopharmacol. Winter. 2001;11(4):377-88. X-1, X-3, X-4. [pmid: 11838820].
2993 Scahill L, McDougle CJ, Williams SK, et al. Children’s Yale-Brown Obsessive Compulsive Scale modified for pervasive developmental disorders. J Am Acad Child Adolesc Psychiatry. 09. 2006;45(9):1114-23. X-4. [pmid: 16926619].
2994 Scanlon K. Art therapy with autistic children. Pratt Institute Creative Arts Therapy Review. 1993;14:34-43. X-2, X-3, X-10.
2995 Scattone D. Social Skills Interventions for Children with Autism. Psychology in the Schools. 09. 2007;44(7):717-726. X-1, X-2, X-3, X-4.
2996 Scattone D. Enhancing the Conversation Skills of a Boy with Asperger’s Disorder through Social Stories[TM] and Video Modeling. Journal of Autism and Developmental Disorders. 02. 2008;38(2):395-400. X-3. [pmid: 17546490].
2997 Scattone D, Tingstrom DH, Wilczynski SM. Increasing Appropriate Social Interactions of Children with Autism Spectrum Disorders Using Social Stories[TM]. Focus on Autism and Other Developmental Disabilities. Win. 2006;21(4):211-222. X-3.
2998 Scattone D, Wilczynski SM, Edwards RP, et al. Decreasing disruptive behaviors of children with autism using social stories. Journal of Autism and Developmental Disorders. 12. 2002;32(6):535-543. X-3. [pmid: 12553590].
2999 Schaaf RC, Miller LJ. Occupational therapy using a sensory integrative approach for children with developmental disabilities. Ment Retard Dev Disabil Res Rev. 2005;11(2):143-8. X-1, X-2, X-3. [pmid: 15977314].
3000 Schaefer GB, Lutz RE. Diagnostic yield in the clinical genetic evaluation of autism spectrum disorders. Genet Med. 09. 2006;8(9):549-56. X-4. [pmid: 16980810].
3001 Schaller J, Yang NK. Competitive Employment for People With Autism: Correlates of Successful Closure in Competitive and Supported Employment. Rehabilitation Counseling Bulletin. Fal. 2005;49(1):4-16. X-1, X-4.
3002 Schatz J, Hamdan-Allen G. Effects of age and IQ on adaptive behavior domains for children with autism. J Autism Dev Disord. 02. 1995;25(1):51-60. X-4, X-10. [pmid: 7608034].
3003 Schechtman MA. Scientifically unsupported therapies in the treatment of young children with autism spectrum disorders. Pediatr Ann. 08. 2007;36(8):497-8. 500. 2. 504. 5. X-1, X-2,X-3, X-4. [pmid: 17849608].
3004 Schepis MM, Reid DH, Fitzgerald JR, et al. A program for increasing manual signing by autistic and profoundly retarded youth within the daily environment. J Appl Behav Anal. Fall. 1982;15(3):363-79. X-3, X-10. [pmid: 7142061].
3005 Scherer NJ, Olswang LB. Using structured discourse as a language intervention technique with autistic children. J Speech Hear Disord. 08. 1989;54(3):383-94. X-3, X-10. [pmid: 2755101].
3006 Schertz H, Robb M. Interventions for Toddlers with Autism: Building on the Parent-Child Relationship to Promote Joint Attention. Young Exceptional Children. 2006;9(3):20-27. X-3.
3007 Schertz HH, Odom SL. Joint Attention and Early Intervention with Autism: A Conceptual Framework and Promising Approaches. Journal of Early Intervention. Fall. 2004;27(1):42-54. X-1, X-2, X-3, X-4.
3008 Schertz HH, Odom SL. Promoting joint attention in toddlers with autism: a parent-mediated developmental model. J Autism Dev Disord. 09. 2007;37(8):1562-75. X-3. [pmid: 17096190].
3009 Schieve LA, Blumberg SJ, Rice C, et al. The relationship between autism and parenting stress. Pediatrics. 02. 2007;119(Suppl 1):S114-21. X-1, X-4. [pmid: 17272578].
3010 Schilling DL, Schwartz IS. Alternative Seating for Young Children with Autism Spectrum Disorder: Effects on Classroom Behavior. Journal of Autism and Developmental Disorders. 2004;34(4):423-432. 08. X-3. [pmid: 15449517].
3011 Schindler HR, Horner RH. Generalized reduction of problem behavior of young children with autism: building trans-situational interventions. Am J Ment Retard. 01. 2005;110(1):36-47. X-3. [pmid: 15568965].
3012 Schleien SJ, Heyne LA, Berken SB. Integrating physical education to teach appropriate play skills to learners with autism: A pilot study. Adapted Physical Activity Quarterly. 07. 1988;5(3):182-192. X-10.
3013 Schleien SJ, Mustonen T, Rynders JE. Participation of children with autism and nondisabled peers in a cooperatively structured community art program. J Autism Dev Disord. 08. 1995;25(4):397-413. X-10. [pmid: 7592251].
3014 Schlinger HD. The Long Good-Bye: Why B. F. Skinner’s “Verbal Behavior” Is Alive and Well on the 50th Anniversary of Its Publication. Psychological Record. Sum. 2008;58(3):329-337. X-1, X-2, X-3, X-4.
3015 Schlosser RW, Blischak DM. Effects of speech and print feedback on spelling by children with autism. J Speech Lang Hear Res. 08. 2004;47(4):848-62. X-3. [pmid: 15324290].
3016 Schlosser RW, Blischak DM, Belfiore PJ, et al. Effects of synthetic speech output and orthographic feedback on spelling in a student with autism: A preliminary study. Journal of Autism and Developmental Disorders. 08. 1998;28(4):309-319. X-10. [pmid: 9711487].
3017 Schlosser RW, Sigafoos J, Luiselli JK, et al. Effects of Synthetic Speech Output on Requesting and Natural Speech Production in Children with Autism: A Preliminary Study. Research in Autism Spectrum Disorders. 04–06. 2007;1(2):139-163. X-3.
3018 Schlosser RW, Wendt O. Effects of augmentative and alternative communication intervention on speech production in children with autism: a systematic review. Am J Speech Lang Pathol. 08. 2008;17(3):212-30. X-2. [pmid: 18663107].
3019 Schmidt GL, Rey MM, Oram Cardy JE, et al. Absence of M100 source asymmetry in autism associated with language functioning. Neuroreport. 07. 15. 2009;20(11):1037-41. X-4. [pmid: 19491710].
3020 Schmidt H, Kern W, Giese R, et al. Intranasal insulin to improve developmental delay in children with 22q13 deletion syndrome: an exploratory clinical trial. J Med Genet. 04. 2009;46(4):217-22. X-1, X-3, X-4. [pmid: 18948358].
3021 Schmidt JG, Dombvoy ML, Watkins K. Treatment of viral encephalitis organic personality disorder and autistic features with propranolol: A case report. Journal of Neurologic Rehabilitation. 1995;9(1):41-45. X-1, X-3, X-4, X-10.
3022 Schmit J, Alper S, Raschke D, et al. Effects of using a photographic cueing package during routine school transitions with a child who has autism. Ment Retard. 04. 2000;38(2):131-7. X-3. [pmid: 10804703].
3023 Schneider CK, Melmed RD, Barstow LE, et al. Oral human immunoglobulin for children with autism and gastrointestinal dysfunction: a prospective, open-label study. J Autism Dev Disord. 11. 2006;36(8):1053-64. X-3. [pmid: 16845577].
3024 Schopler E. Evolution in understanding and treatment of autism. Triangle. 1982;21(2–3):51-7. X-10. [pmid: 7164155].
3025 Schopler E. Treatment abuse and its reduction. J Autism Dev Disord. 06. 1986;16(2):99-104. X-10. [pmid: 3722122].
3026 Schopler E. Specific and nonspecific factors in the effectiveness of a treatment system. Am Psychol. 04. 1987;42(4):376-83. X-10. [pmid: 3605819].
3027 Schopler E. Collaboration between research professional and consumer. J Autism Dev Disord. 04. 1996;26(2):277-80. X-10. [pmid: 8744497].
3028 Schopler E, Dalldorf J. Autism: definition, diagnosis, and management. Hosp Pract. 06. 1980;15(6):64-73. X-1, X-2, X-3, X-4, X-10. [pmid: 7399485].
3029 Schopler E, Hennike JM. Past and present trends in residential treatment. J Autism Dev Disord. 09. 1990;20(3):291-8. X-1, X-2, X-3, X-4, X-10. [pmid: 1699923].
3030 Schopler E, Mesibov G, Baker A. Evaluation of treatment for autistic children and their parents. J Am Acad Child Psychiatry. 05. 1982;21(3):262-7. X-10. [pmid: 7096846].
3031 Schopler E, Olley JG. Public school programing for autistic children. Except Child. 03. 1980;46(6):461-3. X-10. [pmid: 7363914].
3032 Schrandt JA, Townsend DB, Poulson CL. Teaching Empathy Skills to Children with Autism. Journal of Applied Behavior Analysis. Spr. 2009;42(1):17-32. X-3. [pmid: 19721727].
3033 Schreck KA. It can be done: An example of a behavioral individualized education program (IEP) for a child with autism. Behavioral Interventions. 10–12. 2000;15(4):279-300. X-3.
3034 Schreck KA, Mazur A. Behavior analyst use of and beliefs in treatments for people with autism. Behavioral Interventions. 07. 2008;23(3):201-212. X-1, X-4.
3035 Schreck KA, Mulick JA, Smith AF. Sleep problems as possible predictors of intensified symptoms of autism. Res Dev Disabil. 01–02. 2004;25(1):57-66. X-4. [pmid: 14733976].
3036 Schreck KA, Williams K. Food P and Factors Influencing Food Selectivity for Children with Autism Spectrum Disorders. Research in Developmental Disabilities: A Multidisciplinary Journal. 07–08. 2006;27(4):353-363. X-1, X-4.
3037 Schreck KA, Williams K, Smith AF. A comparison of eating behaviors between children with and without autism. J Autism Dev Disord. 08. 2004;34(4):433-8. X-1, X-4. [pmid: 15449518].
3038 Schreibman L. Intensive behavioral/psychoeducational treatments for autism: research needs and future directions. J Autism Dev Disord. 10. 2000;30(5):373-8. X-1, X-2, X-3, X-4. [pmid: 11098871].
3039 Schreibman L, Charlop MH, Koegel RL. Teaching autistic children to use extra-stimulus prompts. J Exp Child Psychol. 06. 1982;33(3):475-91. X-10. [pmid: 7097156].
3040 Schreibman L, Kaneko WM, Koegel RL. Positive affect of parents of autistic children: A comparison across two teaching techniques. Behavior Therapy. Fal. 1991;22(4):479-490. X-10.
3041 Schreibman L, O’Neill RE, Koegel RL. Behavioral training for siblings of autistic children. J Appl Behav Anal. Summer. 1983;16(2):129-38. X-10. [pmid: 6885667].
3042 Schreibman L, Stahmer AC, Barlett VC, et al. Brief Report: Toward Refinement of a Predictive Behavioral Profile for Treatment Outcome in Children with Autism. Research in Autism Spectrum Disorders. 01. 2009;3(1):163-172. X-3. [pmid: 20046210].
3043 Schreibman L, Whalen C, Stahmer AC. The use of video priming to reduce disruptive transition behavior in children with autism. Journal of Positive Behavior Interventions. Win. 2000;2(1):3-11. X-3.
3044 Schroeder CS, Schroeder SR. The future of children is now. J Autism Dev Disord. 09. 1990;20(3):367-78. X-1, X-2, X-3, X-4, X-10. [pmid: 1699924].
3045 Schroeder SR, LeBlanc JM, Mayo L. Brief report: a life-span perspective on the development of individuals with autism. J Autism Dev Disord. 04. 1996;26(2):251-5. X-10. [pmid: 8744495].
3046 Schroeder SR, Mulick JA, Rojahn J. The definition, taxonomy, epidemiology, and ecology of self-injurious behavior. J Autism Dev Disord. 12. 1980;10(4):417-32. X-1, X-2, X-3, X-4, X-10. [pmid: 6985454].
3047 Schubert A. “I want to talk like everyone”: on the use of multiple means of communication. Ment Retard. 10. 1997;35(5):347-54. X-3, X-4, X-10. [pmid: 9339063].
3048 Schultz ST, Klonoff-Cohen HS, Wingard DL, et al. Acetaminophen (Paracetamol) Use, Measles-Mumps-Rubella Vaccination, and Autistic Disorder: The Results of a Parent Survey. Autism: The International Journal of Research and Practice. 2008;12(3):293-307. X-1, X-4. [pmid: 18445737].
3049 Schumacher K. Informed consent: should it be extended to vaccinations?. Thomas Jefferson Law Rev. Fall. 1999;22(1):89-119. X-10. [pmid: 15732182].
3050 Schuntermann P. Pervasive developmental disorder and parental adaptation: previewing and reviewing atypical development with parents in child psychiatric consultation. Harv Rev Psychiatry. 01–02. 2002;10(1):16-27. X-4. [pmid: 11751642].
3051 Schwarte AR. Fragile X Syndrome. School Psychology Quarterly. 06. 2008;23(2):290-300. X-1, X-2, X-3, X-4.
3052 Schwartz CB, Henderson HA, Inge AP, et al. Temperament as a Predictor of Symptomotology and Adaptive Functioning in Adolescents with High-Functioning Autism. Journal of Autism and Developmental Disorders. 06. 2009;39(6):842-855. X-1, X-4. [pmid: 19165586].
3053 Schwartz H, Drager KD. Training and knowledge in autism among speech-language pathologists: a survey. Lang Speech Hear Serv Sch. 01. 2008;39(1):66-77. X-1, X-4. [pmid: 18162649].
3054 Schwartz IS, Sandall SR, Garfinkle AN, et al. Outcomes for children with autism: Three case studies. Topics in Early Childhood Special Education. Fal. 1998;18(3):132-143. X-3, X-10.
3055 Schwichtenberg A, Poehlmann J. Applied behaviour analysis: does intervention intensity relate to family stressors and maternal well-being?. J Intellect Disabil Res. 08. 2007;51(Pt 8):598-605. X-1, X-4. [pmid: 17598873].
3056 Scifo R, Batticane N, Quattropani MC, et al. A double-blind trial with naltrexone in autism. Brain Dysfunction. 11–12. 1991;4(6):301-307. X-10.
3057 Scifo R, Cioni M, Nicolosi A, et al. Opioid-immune interactions in autism: behavioural and immunological assessment during a double-blind treatment with naltrexone. Ann Ist Super Sanita. 1996;32(3):351-9. X-10. [pmid: 9028057].
3058 Scolnick B. Effects of electroencephalogram biofeedback with Asperger’s syndrome. Int J Rehabil Res. 06. 2005;28(2):159-63. X-1, X-3. [pmid: 15900187].
3059 Scorgie K, Wilgosh L. Reflections on an Uncommon Journey: A Follow-Up Study of Life Management of Six Mothers of Children with Diverse Disabilities. International Journal of Special Education. 2008;23(1):103-114. X-1, X-4.
3060 Scott DW, Eames P. Use of sulpiride in a case of atypical autism. Journal of Autism and Developmental Disorders. 03. 1988;18(1):144-146. X-1, X-3, X-10. [pmid: 3372456].
3061 Scott FJ, Baron-Cohen S, Bolton P, et al. The CAST (Childhood Asperger Syndrome Test): preliminary development of a UK screen for mainstream primary-school-age children. Autism. 03. 2002;6(1):9-31. X-1, X-4. [pmid: 11918111].
3062 Scott MA, Fletcher JM, Brookshire BL, et al. Memory functions in children with early hydrocephalus. Neuropsychology. 10. 1998;12(4):578-89. X-4, X-10. [pmid: 9805328].
3063 Scragg P, Shah A. Prevalence of Asperger’s syndrome in a secure hospital. Br J Psychiatry. 11. 1994;165(5):679-82. X-4, X-10. [pmid: 7794327].
3064 Seabert H, Eastwood EC, Harris A. A multiprofessional children’s feeding clinic. J Fam Health Care. 2005;15(3):72-4. X-1, X-2, X-3, X-4. [pmid: 16094900].
3065 Seal BC, Bonvillian JD. Sign language and motor functioning in students with autistic disorder. J Autism Dev Disord. 08. 1997;27(4):437-66. X-4, X-10. [pmid: 9261668].
3066 Searles HF. Separation and loss in psychoanalytic therapy with borderline patients: further remarks. Am J Psychoanal. Spring. 1985;45(1):9-34. X-1, X-2, X-3, X-4, X-10. [pmid: 3993826].
3067 Sebestik J, Garralda ME. Survey of difficult to contain and treat children and adolescents. Arch Dis Child. 07. 1996;75(1):78-81. X-1, X-4, X-10. [pmid: 8813878].
3068 Secan KE, Egel AL, Tilley CS. Acquisition, generalization, and maintenance of question-answering skills in autistic children. J Appl Behav Anal. Summer. 1989;22(2):181-96. X-10. [pmid: 2745239].
3069 Seida JK, Ospina MB, Karkhaneh M, et al. Systematic reviews of psychosocial interventions for autism: an umbrella review. Dev Med Child Neurol. 02. 2009;51(2):95-104. X-2. [pmid: 19191842].
3070 Selassie GR-H, Viggedal G, Olsson I, et al. Speech, Language, and Cognition in Preschool Children with Epilepsy. Developmental Medicine & Child Neurology. 06. 2008;50(6):432-438. X-1, X-4. [pmid: 18422681].
3071 Sen E, Yurtsever S. Difficulties experienced by families with disabled children. J Spec Pediatr Nurs. 10. 2007;12(4):238-52. X-1, X-4. [pmid: 17956372].
3072 Serra M, Minderaa RB, van Geert PL, et al. Social-cognitive abilities in children with lesser variants of autism: skill deficits or failure to apply skills?. Eur Child Adolesc Psychiatry. 12. 1999;8(4):301-11. X-4, X-10. [pmid: 10654124].
3073 Serra M, Minderaa RB, van Geert PL, et al. Emotional role-taking abilities of children with a pervasive developmental disorder not otherwise specified. J Child Psychol Psychiatry. 03. 1995;36(3):475-90. X-4, X-10. [pmid: 7782410].
3074 Serrano AC. Haloperidol -- its use in children. J Clin Psychiatry. 04. 1981;42(4):154-6. X-1, X-2, X-3, X-4, X-10. [pmid: 6937455].
3075 Sersen EA, Heaney G, Clausen J, et al. Brainstem auditory-evoked responses with and without sedation in autism and Down’s syndrome. Biological Psychiatry. 04. 1990;27(8):834-840. X-4, X-10. [pmid: 2139583].
3076 Servais Vr. Some comments on context embodiment in zootherapy: The case of the Autidolfin project. AnthrozoÃ¶s. 1999;12(1):5-15. X-10.
3077 Seung H, Rogalski Y, Shankar M, et al. The gluten- and casein-free diet and autism: Communication outcomes from a preliminary double-blind clinical trial. Journal of Medical Speech-Language Pathology. 12. 2007;15(4):337-345. X-3.
3078 Seung HK, Ashwell S, Elder JH, et al. Verbal communication outcomes in children with autism after in-home father training. J Intellect Disabil Res. 02. 2006;50(Pt 2):139-50. X-3. [pmid: 16403202].
3079 Sevy S, Nathanson K, Visweswaraiah H, et al. The relationship between insight and symptoms in schizophrenia. Compr Psychiatry. 01–02. 2004;45(1):16-9. X-4. [pmid: 14671732].
3080 Sgro MD, Barozzino T, Mirghani HM, et al. Pregnancy outcome post renal transplantation. Teratology. 01. 2002;65(1):5-9. X-1, X-2, X-4. [pmid: 11835226].
3081 Shabani DB, Fisher WW. Stimulus fading and differential reinforcement for the treatment of needle phobia in a youth with autism. Journal of Applied Behavior Analysis. Win. 2006;39(4):449-452. X-3. [pmid: 17236343].
3082 Shabani DB, Katz RC, Wilder DA, et al. Increasing social initiations in children with autism: effects of a tactile prompt. J Appl Behav Anal. Spring. 2002;35(1):79-83. X-3. [pmid: 11936550].
3083 Shabani DB, Wilder DA, Flood WA. Reducing stereotypic behavior through discrimination training, differential reinforcement of other behavior, and self monitoring. Behavioral Interventions. 10–12. 2001;16(4):279-286. X-3.
3084 Shabry F, Wolk JA. Granulocytopenia in children after phenothiazine therapy. Am J Psychiatry. 03. 1980;137(3):374-5. X-10. [pmid: 6101935].
3085 Shafer MS, Egel AL, Neef NA. Training mildly handicapped peers to facilitate changes in the social interaction skills of autistic children. J Appl Behav Anal. Winter. 1984;17(4):461-76. X-4, X-10. [pmid: 6526767].
3086 Shah A, Parikh D, Jawaheer G, et al. Persistent rectal prolapse in children: sclerotherapy and surgical management. Pediatr Surg Int. 04. 2005;21(4):270-3. X-1, X-4. [pmid: 15761711].
3087 Shaked M, Bilu Y. Grappling with affliction: Autism in the Jewish ultraorthodox community in Israel. Culture, Medicine and Psychiatry. 03. 2006;30(1):1-27. X-1, X-2, X-3, X-4.
3088 Sham E, Seuntjens J, Devic S, et al. Influence of focal spot on characteristics of very small diameter radiosurgical beams. Med Phys. 07. 2008;35(7):3317-30. X-1, X-2, X-3, X-4. [pmid: 18697556].
3089 Shannon M, Graef JW. Lead intoxication in children with pervasive developmental disorders. J Toxicol Clin Toxicol. 1996;34(2):177-81. X-4, X-10. [pmid: 8618251].
3090 Shapira J, Mann J, Tamari I, et al. Oral health status and dental needs of an autistic population of children and young adults. Spec Care Dentist. 03–04. 1989;9(2):38-41. X-4, X-10. [pmid: 2533709].
3091 Shapiro T, Frosch E, Arnold S. Communicative interaction between mothers and their autistic children: application of a new instrument and changes after treatment. J Am Acad Child Adolesc Psychiatry. 07. 1987;26(4):485-90. X-10. [pmid: 3654498].
3092 Shattuck PT, Grosse S, Parish S, et al. Utilization of a Medicaid-funded intervention for children with autism. Psychiatr Serv. 04. 2009;60(4):549-52. X-3, X-4. [pmid: 19339334].
3093 Shavelle RM, Strauss D. Comparative mortality of persons with autism in California, 1980–1996. J Insur Med. 1998;30(4):220-5. X-4, X-10. [pmid: 10537926].
3094 Shaw P, Rapoport JL. Decision Making about Children with Psychotic Symptoms: Using the Best Evidence in Choosing a Treatment. Journal of the American Academy of Child and Adolescent Psychiatry. 11. 2006;45(11):1381. X-1, X-3, X-4. [pmid: 17075361].
3095 Shea V. A Perspective on the Research Literature Related to Early Intensive Behavioral Intervention (Lovaas) for Young Children with Autism. Autism The International Journal of Research and Practice. 12. 2004;8(4):349-367. X-1, X-2, X-3, X-4. [pmid: 15556956].
3096 Shea V. A Perspective on the Research Literature Related to Early Intensive Behavioral Intervention (Lovaas) for Young Children with Autism. Communication Disorders Quarterly. Win. 2005;26(2):102-111. X-1, X-2, X-3, X-4.
3097 Shearer DD, et al. Promoting independent interactions between preschoolers with autism and their nondisabled peers: An analysis of self-monitoring. Early Education and Development. 07. 1996;7(3):205-220. X-10.
3098 Sheehan CM, Matuozzi RT. Investigation of the validity of facilitated communication through the disclosure of unknown information. Mental Retardation. 04. 1996;34(2):94-107. X-10. [pmid: 8935889].
3099 Sheinkopf SJ, Siegel B. Home-based behavioral treatment of young children with autism. J Autism Dev Disord. 02. 1998;28(1):15-23. X-10. [pmid: 9546298].
3100 Sheitman BB, Knable MB, Jarskog LF, et al. Secretin for refractory schizophrenia. Schizophr Res. 02. 1. 2004;66(2–3):177-81. X-1, X-3, X-4. [pmid: 15061251].
3101 Shek DT, Tsang SK, Lam LL, et al. Psychometric properties of the Chinese version of the Psycho-educational Profile-Revised (CPEP-R). J Autism Dev Disord. 02. 2005;35(1):37-44. X-1, X-2, X-4. [pmid: 15796120].
3102 Sherer M, Pierce KL, Paredes S, et al. Enhancing conversation skills in children with autism via video technology. Which is better, “self” or “other” as a model?. Behav Modif. 01. 2001;25(1):140-58. X-3. [pmid: 11151482].
3103 Sherer MR, Schreibman L. Individual behavioral profiles and predictors of treatment effectiveness for children with autism. J Consult Clin Psychol. 06. 2005;73(3):525-38. X-3. [pmid: 15982150].
3104 Sherman BR. Predictors of the decision to place developmentally disabled family members in residential care. Am J Ment Retard. 01. 1988;92(4):344-51. X-1, X-4, X-10. [pmid: 3342136].
3105 Sherman J, Barker P, Lorimer P, et al. Treatment of autistic children: relative effectiveness of residential, out-patient and home-based interventions. Child Psychiatry Hum Dev. Winter. 1988;19(2):109-25. X-10. [pmid: 3229155].
3106 Sherman J, Factor DC, Swinson R, et al. The effects of fenfluramine (hydrochloride) on the behaviors of fifteen autistic children. J Autism Dev Disord. 12. 1989;19(4):533-43. X-10. [pmid: 2606883].
3107 Sherratt D. Developing pretend play in children with autism: a case study. Autism. 06. 2002;6(2):169-79. X-3. [pmid: 12083283].
3108 Sheth RD, Goulden KJ, Ronen GM. Aggression in children treated with clobazam for epilepsy. Clin Neuropharmacol. 08. 1994;17(4):332-7. X-10. [pmid: 9316680].
3109 Shevell M, Majnemer A, Platt RW, et al. Developmental and functional outcomes in children with global developmental delay or developmental language impairment. Dev Med Child Neurol. 10. 2005;47(10):678-83. X-4. [pmid: 16174311].
3110 Shields J. The NAS EarlyBird Programme: autism-specific early intervention for parents. Prof Care Mother Child. 2000;10(2):53-4. X-1, X-2, X-3, X-4. [pmid: 11040767].
3111 Shields J. The NAS EarlyBird Programme: partnership with parents in early intervention. The National Autistic Society. Autism. 03. 2001;5(1):49-56. X-1, X-2, X-3, X-4. [pmid: 11708389].
3112 Shields-Wolfe J, Gallagher PA. Functional utilization of splinter skills for the employment of a young adult with autism. Focus on Autistic Behavior. 10. 1992;7(4):1-16. X-1, X-3, X-10.
3113 Shimoji T, Shimabukuro S, Sugama S, et al. Mild trigonocephaly with clinical symptoms: analysis of surgical results in 65 patients. Childs Nerv Syst. 05. 2002;18(5):215-24. X-1, X-3, X-4. [pmid: 12042920].
3114 Shimoji T, Tomiyama N. Mild trigonocephaly and intracranial pressure: report of 56 patients. Childs Nerv Syst. 10. 2004;20(10):749-56. X-4. [pmid: 15185114].
3115 Shipley-Benamou R, Lutzker JR, Taubman M. Teaching daily living skills to children with autism through instructional video modeling. Journal of Positive Behavior Interventions. Sum. 2002;4(3):165-175. X-3.
3116 Shirataki S, Hanada M, Kuromaru S, et al. Long-term follow-up study of 13 autistic children. Folia Psychiatr Neurol Jpn. 1984;38(1):25-31. X-4, X-10. [pmid: 6537390].
3117 Shireman TI, Reichard A, Rigler SK. Psychotropic medication use among Kansas Medicaid youths with disabilities. J Child Adolesc Psychopharmacol. 02. 2005;15(1):107-15. X-1, X-4. [pmid: 15741792].
3118 Shook GL, Ala’i-Rosales S, Glenn SS. Training and certifying behavior analysts. Behav Modif. 01. 2002;26(1):27-48. X-1, X-2, X-3, X-4. [pmid: 11799652].
3119 Shook GL, Neisworth JT. Ensuring Appropriate Qualifications for Applied Behavior Analyst Professionals: The Behavior Analyst Certification Board. Exceptionality. 03. 2005;13(1):3-10. X-1, X-2, X-3, X-4.
3120 Short AB. Short-term treatment outcome using parents as co-therapists for their own autistic children. J Child Psychol Psychiatry. 07. 1984;25(3):443-58. X-10. [pmid: 6746793].
3121 Shu BC, Lung FW. The effect of support group on the mental health and quality of life for mothers with autistic children. J Intellect Disabil Res. 01. 2005;49(Pt 1):47-53. X-1, X-4. [pmid: 15634311].
3122 Shuttleworth J. The suffering of Asperger children and the challenge they present to psychoanalytic thinking. Journal of Child Psychotherapy. 08. 1999;25(2):239-265. X-3, X-10.
3123 Siaperas P, Beadle-Brown J. A case study of the use of a structured teaching approach in adults with autism in a residential home in Greece. Autism. 07. 2006;10(4):330-43. X-1, X-3, X-4. [pmid: 16908477].
3124 Sidener TM, Carr JE, Firth AM. Superimposition and withholding of edible consequences as treatment for automatically reinforced stereotypy. J Appl Behav Anal. Spring. 2005;38(1):121-4. X-3. [pmid: 15898482].
3125 Sidener TM, Shabani DB, Carr JE, et al. An evaluation of strategies to maintain mands at practical levels. Res Dev Disabil. 11–12. 2006;27(6):632-44. X-3. [pmid: 16298103].
3126 Sidoli M. The little puppet: working with autistic defences in mother-infant psychotherapy. J Anal Psychol. 04. 2000;45(2):159-75. X-3, X-4. [pmid: 14533392].
3127 Sigafoos J. Assessing conditional use of graphic mode requesting in a young boy with autism. Journal of Developmental and Physical Disabilities. 06. 1998;10(2):133-151. X-10.
3128 Sigafoos J, Didden R, O’Reilly M. Effects of speech output on maintenance of requesting and frequency of vocalizations in three children with developmental disabilities. AAC: Augmentative and Alternative Communication. 03. 2003;19(1):37-47. X-3.
3129 Sigafoos J, Drasgow E, Halle JW, et al. Teaching VOCA use as a communicative repair strategy. J Autism Dev Disord. 08. 2004;34(4):411-22. X-3. [pmid: 15449516].
3130 Sigafoos J, Ganz J, O’Reilly M, et al. Evidence-Based Practice in the Classroom: Evaluating a Procedure for Reducing Perseverative Requesting in an Adolescent with Autism and Severe Intellectual Disability. Australasian Journal of Special Education. 04. 2008;32(1):55-65. X-3.
3131 Sigafoos J, Ganz JB, O’Reilly M, et al. Assessing Correspondence Following Acquisition of an Exchange-Based Communication System, Research in Developmental Disabilities: A Multidisciplinary Journal Journal Citation. 01–02. 2007;28(1):71-83. Publisher: Elsevier. 6277 Sea Harbor Drive, Orlando, FL 32887-4800. Tel: 877-839-7126; Tel: 407-345-4020; Fax: 407-363-1354; e-mail: usjcs@elsevier.com; Web site: http://www.elsevier.com. 2007 Pub Types: Journal Articles; Reports - Evaluative. X-3.
3132 Sigafoos J, Green VA, Schlosser R, et al. Communication Intervention in Rett Syndrome: A Systematic Review. Research in Autism Spectrum Disorders. 04–06. 2009;3(2):304-318. X-1, X-2, X-3, X-4.
3133 Sigafoos J, Kerr M, Roberts D, et al. Increasing opportunities for requesting in classrooms serving children with developmental disabilities. J Autism Dev Disord. 10. 1994;24(5):631-45. X-10. [pmid: 7814311].
3134 Sigafoos J, Meikle B. Functional communication training for the treatment of multiply determined challenging behavior in two boys with autism. Behavior Modification. 01. 1996;20(1):60-84. X-3, X-10. [pmid: 8561770].
3135 Sigafoos J, O’Reilly M, Ma CH, et al. Effects of Embedded Instruction Versus Discrete-Trial Training on Self-Injury, Correct Responding, and Mood in a Child with Autism. Journal of Intellectual and Developmental Disability. 12. 2006;31(4):196-203. X-3. [pmid: 17178531].
3136 Sigafoos J, O’Reilly M, Seely-York S, et al. Teaching students with developmental disabilities to locate their AAC device. Res Dev Disabil. 07–08. 2004;25(4):371-83. X-3. [pmid: 15193671].
3137 Sigafoos J, Roberts D, Kerr M, et al. Opportunities for communication in classrooms serving children with developmental disabilities. J Autism Dev Disord. 06. 1994;24(3):259-79. X-10. [pmid: 8050981].
3138 Sigafoos J, Roberts-Pennell D, Graves D. Longitudinal assessment of play and adaptive behavior in young children with developmental disabilities. Res Dev Disabil. 03–04. 1999;20(2):147-61. X-4, X-10. [pmid: 10198944].
3139 Sigman M, McGovern CW. Improvement in cognitive and language skills from preschool to adolescence in autism. J Autism Dev Disord. 02. 2005;35(1):15-23. X-4. [pmid: 15796118].
3140 Sigman M, Ruskin E, Arbeile S, et al. Continuity and change in the social competence of children with autism, Down syndrome, and developmental delays. Monogr Soc Res Child Dev. 1999;64(1):1-114. X-4, X-10.
3141 Sigman M, Ungerer JA. Cognitive and language skills in autistic, mentally retarded, and normal children. Developmental Psychology. 03. 1984;20(2):293-302. X-10.
3142 Sik Lanyi C, Laky V, Tilinger A, et al. Developing multimedia software and virtual reality worlds and their use in rehabilitation and psychology. Stud Health Technol Inform. 2004;105:273-84. X-1, X-2, X-3, X-4. [pmid: 15718616].
3143 Siller M, Sigman M. The behaviors of parents of children with autism predict the subsequent development of their children’s communication. J Autism Dev Disord. 04. 2002;32(2):77-89. X-4. [pmid: 12058846].
3144 Siller M, Sigman M. Modeling longitudinal change in the language abilities of children with autism: parent behaviors and child characteristics as predictors of change. Dev Psychol. 11. 2008;44(6):1691-704. X-4. [pmid: 18999331].
3145 Silva LM, Cignolini A. A medical qigong methodology for early intervention in autism spectrum disorder: a case series. Am J Chin Med. 2005;33(2):315-27. X-3. [pmid: 15974490].
3146 Silva RR, Malone RP, Anderson LT, et al. Haloperidol withdrawal and weight changes in autistic children. Psychopharmacol Bull. 1993;29(2):287-91. X-4, X-10. [pmid: 8290679].
3147 Silveira R, Jainer AK, Bates G. Fluoxetine treatment of selective mutism in pervasive developmental disorder. International Journal of Psychiatry in Clinical Practice. 09. 2004;8(3):179-180. X-3.
3148 Silver H, Goodman C, Knoll G, et al. Brief emotion training improves recognition of facial emotions in chronic schizophrenia. A pilot study. Psychiatry Res. 09. 30. 2004;128(2):147-54. X-1, X-4. [pmid: 15488957].
3149 Silver M, Oakes P. Evaluation of a new computer intervention to teach people with autism or Asperger syndrome to recognize and predict emotions in others. Autism. 09. 2001;5(3):299-316. X-1. [pmid: 11708589].
3150 Silverman RD. Litigation, regulation, and education--protecting the public’s health through childhood immunization. N Engl J Med. 06. 11. 2009;360(24):2500-1. X-1, X-2, X-3, X-4. [pmid: 19516031].
3151 Simer N, Cuvo AJ. Training Vision Screening Behavior to Children with Developmental Disabilities. Research in Autism Spectrum Disorders. 04–06. 2009;3(2):409-420. X-3.
3152 Simon EW, Whitehair PM, Toll DM. A case study: Follow-up assessment of facilitated communication. Journal of Autism and Developmental Disorders. 02. 1996;26(1):9-18. X-10. [pmid: 8819768].
3153 Simonson LR, Simonson SM, Volkmar FR. Benhaven’s residential program. J Autism Dev Disord. 09. 1990;20(3):323-37. X-1, X-2, X-3, X-4, X-10. [pmid: 2228915].
3154 Simpson A, Langone J, Ayres KM. Embedded Video and Computer Based Instruction to Improve Social Skills for Students with Autism. Education and Training in Developmental Disabilities. 09. 2004;39(3):240-252. X-3.
3155 Simpson R. Tips for practitioners: Reinforcement of social story compliance. Focus on Autistic Behavior. 08. 1993;8(3):15-16. X-10.
3156 Simpson RL. Finding Effective Intervention and Personnel Preparation Practices for Students with Autism Spectrum Disorders. Exceptional Children. Win. 2004;70(2):135-144. X-1, X-2, X-3, X-4.
3157 Simpson RL, McKee M, Teeter D, et al. Evidence-Based Methods for Children and Youth with Autism Spectrum Disorders: Stakeholder Issues and Perspectives. Exceptionality. 11. 2007;15(4):203-217. X-1, X-2, X-3, X-4.
3158 Simpson RL, Myles BS. Effectiveness of facilitated communication with children and youth with autism. The Journal of Special Education. Win. 1995;28(4):424-439. X-10.
3159 Singh I. Prolonged oculogyric crisis on addition of nifedipine to neuroleptic medication regime. British Journal of Psychiatry. 01. 1987;150:127-128. X-1, X-3, X-10. [pmid: 3651662].
3160 Singh J, Illes J, Lazzeroni L, et al. Trends in US autism research funding. J Autism Dev Disord. 05. 2009;39(5):788-95. X-1, X-2, X-3, X-4. [pmid: 19148735].
3161 Singh NN, Lancioni GE, Winton AS, et al. Mindful parenting decreases aggression and increases social behavior in children with developmental disabilities. Behav Modif. 11. 2007;31(6):749-71. X-1, X-3, X-4. [pmid: 17932234].
3162 Singh NN, Lancioni GE, Winton ASW, et al. Mindful Parenting Decreases Aggression, Noncompliance, and Self-Injury in Children with Autism. Journal of Emotional and Behavioral Disorders. Fall. 2006;14(3):169-177. X-1, X-3, X-4.
3163 Singh VK, Jensen RL. Elevated levels of measles antibodies in children with autism. Pediatr Neurol. 04. 2003;28(4):292-4. X-4. [pmid: 12849883].
3164 Sinha Y, Silove N, Wheeler D, et al. Auditory integration training and other sound therapies for autism spectrum disorders. Cochrane Database Syst Rev. 2004;(1):CD003681. X-2.
3165 Sinha Y, Silove N, Wheeler D, et al. Auditory integration training and other sound therapies for autism spectrum disorders: a systematic review. Arch Dis Child. 12. 2006;91(12):1018-22. X-2. [pmid: 16887860].
3166 Sjogreen L, Andersson-Norinder J, Jacobsson C. Development of speech, feeding, eating, and facial expression in Mobius sequence. Int J Pediatr Otorhinolaryngol. 09. 28. 2001;60(3):197-204. X-1, X-4. [pmid: 11551610].
3167 Sloan JL, Marcus L. Some findings on the use of the adaptive behavior scale with autistic children. J Autism Dev Disord. 06. 1981;11(2):191-9. X-1, X-2, X-3, X-4, X-10. [pmid: 6927704].
3168 Slotnick CF. Cognitive differences in classification tasks among autistic children. New Dir Child Dev. Spring. 1988;(39):75-90. X-10.
3169 Smith A, McCann R, McKinlay I. Second dose of MMR vaccine: health professionals’ level of confidence in the vaccine and attitudes towards the second dose. Commun Dis Public Health. 12. 2001;4(4):273-7. X-1, X-4. [pmid: 12109394].
3170 Smith A, Yarwood J, Salisbury DM. Tracking mothers’ attitudes to MMR immunisation 1996–2006. Vaccine. 05. 16. 2007;25(20):3996-4002. X-1, X-4. [pmid: 17395344].
3171 Smith AE, Camarata S. Using teacher-implemented instruction to increase language intelligibility of children with autism. Journal of Positive Behavior Interventions. Sum. 1999;1(3):141-151. X-10.
3172 Smith B, Chung MC, Vostanis P. The path to care in autism: is it better now?. J Autism Dev Disord. 10. 1994;24(5):551-63. X-1, X-4, X-10. [pmid: 7814305].
3173 Smith C, Felce D, Jones E, et al. Responsiveness to staff support: evaluating the impact of individual characteristics on the effectiveness of active support training using a conditional probability approach. J Intellect Disabil Res. 11. 2002;46(Pt 8):594-604. X-1. [pmid: 12427166].
3174 Smith DE, McConnell JV, Walter TL, et al. Effect of using an auditory trainer on the attentional, language, and social behaviors of autistic children. J Autism Dev Disord. 09. 1985;15(3):285-302. X-10. [pmid: 4030662].
3175 Smith EG, Bennetto L. Audiovisual speech integration and lipreading in autism. J Child Psychol Psychiatry. 08. 2007;48(8):813-21. X-4. [pmid: 17683453].
3176 Smith GJ, McDougall D, Edelen-Smith P. Behavioral Cusps: A Person-Centered Concept for Establishing Pivotal Individual, Family, and Community Behaviors and Repertoires. Focus on Autism and Other Developmental Disabilities. Win. 2006;21(4):223-229. X-1, X-2, X-3, X-4.
3177 Smith IM, Bryson SE. Gesture imitation in autism: II. Symbolic gestures and pantomimed object use. Cognitive Neuropsychology. 2007;24(7):679-700. X-1, X-3. [pmid: 18066731].
3178 Smith LE, Greenberg JS, Seltzer MM, et al. Symptoms and Behavior Problems of Adolescents and Adults with Autism: Effects of Mother-Child Relationship Quality, Warmth, and Praise. American Journal on Mental Retardation. 09. 2008;113(5):387-402. X-1, X-4. [pmid: 18702558].
3179 Smith MD. Use of similar sensory stimuli in the community-based treatment of self-stimulatory behavior in an adult disabled by autism. Journal of Behavior Therapy and Experimental Psychiatry. 06. 1986;17(2):121-125. X-1, X-3, X-10. [pmid: 3722396].
3180 Smith MD, Belcher R. Teaching life skills to adults disabled by autism. Journal of Autism and Developmental Disorders. 06. 1985;15(2):163-175. X-1, X-3, X-10. [pmid: 3997743].
3181 Smith MD, Belcher RG. Brief report: facilitated communication with adults with autism. J Autism Dev Disord. 03. 1993;23(1):175-83. X-10. [pmid: 8463197].
3182 Smith MD, Coleman D. Managing the behavior of adults with autism in the job setting. Journal of Autism and Developmental Disorders. 06. 1986;16(2):145-154. X-1, X-3, X-10. [pmid: 3722116].
3183 Smith MD, Haas PJ, Belcher RG. Facilitated communication: the effects of facilitator knowledge and level of assistance on output. J Autism Dev Disord. 06. 1994;24(3):357-67. X-1, X-10. [pmid: 8050988].
3184 Smith MJ, Ellenberg SS, Bell LM, et al. Media coverage of the measles-mumps-rubella vaccine and autism controversy and its relationship to MMR immunization rates in the United States. Pediatrics. 04. 2008;121(4):e836-43. X-1, X-2, X-3, X-4. [pmid: 18381512].
3185 Smith MJ, Woods CR, Marshall GS. Parental vaccine concerns in Kentucky. J Ky Med Assoc. 09. 2009;107(9):342-9. X-1, X-3, X-4. [pmid: 19813430].
3186 Smith MR, Lerman DC. A preliminary comparison of guided compliance and high-probability instructional sequences as treatment for noncompliance in children with developmental disabilities. Research in Developmental Disabilities. 05–06. 1999;20(3):183-195. X-3, X-10. [pmid: 10372411].
3187 Smith SA, Press B, Koenig KP, et al. Effects of sensory integration intervention on self-stimulating and self-injurious behaviors. Am J Occup Ther. 07–08. 2005;59(4):418-25. X-3. [pmid: 16124208].
3188 Smith SG, Gupta KK, Smith SH. Effects of naltrexone on self-injury, stereotypy, and social behavior of adults with developmental disabilities. Journal of Developmental and Physical Disabilities. Special Issue: Pharmacotherapy III. 06. 1995;7(2):137-146. X-1, X-3, X-10.
3189 Smith T. Improving memory to promote maintenance of treatment gains in children with autism. Psychological Record. Fal. 1994;44(4):459-473. X-3, X-10.
3190 Smith T. Discrete Trial Training in the Treatment of Autism. Focus on Autism and Other Developmental Disabilities. 2001. X-1, X-2, X-3, X-4.
3191 Smith T, Antolovich M. Parental perceptions of supplemental interventions received by young children with autism in intensive behavior analytic treatment. Behavioral Interventions. 04–06. 2000;15(2):83-97. X-1, X-2, X-3, X-4.
3192 Smith T, Buch GA, Gamby TE. Parent-directed, intensive early intervention for children with pervasive developmental disorder. Res Dev Disabil. 07–08. 2000;21(4):297-309. X-3. [pmid: 10983784].
3193 Smith T, Eikeseth S, Klevstrand M, et al. Intensive behavioral treatment for preschoolers with severe mental retardation and pervasive developmental disorder. Am J Ment Retard. 11. 1997;102(3):238-49. X-10. [pmid: 9394133].
3194 Smith T, Lovaas NW, Lovaas OI. Behaviors of children with high-functioning autism when paired with typically developing versus delayed peers: A preliminary study. Behavioral Interventions. 07–09. 2002;17(3):129-143. X-6.
3195 Smith T, Mruzek DW, Wheat LA, et al. Error correction in discrimination training for children with autism. Behavioral Interventions. 11. 2006;21(4):245-263. X-3.
3196 Smith T, Scahill L, Dawson G, et al. Designing Research Studies on Psychosocial Interventions in Autism. Journal of Autism and Developmental Disorders. 02. 2007;37(2):354-366. X-1, X-2, X-3, X-4. [pmid: 16897380].
3197 Smith V, Mirenda P, Zaidman-Zait A. Predictors of Expressive Vocabulary Growth in Children with Autism. Journal of Speech, Language, and Hearing Research. 02. 2007;50(1):149-160. X-4.
3198 Smukler D. Unauthorized minds: how “theory of mind” theory misrepresents autism. Ment Retard. 02. 2005;43(1):11-24. X-1, X-2, X-3, X-4. [pmid: 15628930].
3199 Smyth P, Hardy N. Evan’s Frequency of Hand-Biting During a Six- Hour School Day. Journal of Precision Teaching & Celeration. Fal. 2002;18(2):67-68. X-3.
3200 Snead RW, Boon F, Presberg J. Paroxetine for self-injurious behavior. Journal of the American Academy of Child & Adolescent Psychiatry. 07–08. 1994;33(6):909-910. X-1, X-3, X-10. [pmid: 8083152].
3201 Snyder A, Bahramali H, Hawker T, et al. Savant-like numerosity skills revealed in normal people by magnetic pulses. Perception. 2006;35(6):837-45. X-1, X-4. [pmid: 16836048].
3202 Snyder A, Bossomaier T, Mitchell DJ. Concept formation: ‘object’ attributes dynamically inhibited from conscious awareness. J Integr Neurosci. 03. 2004;3(1):31-46. X-1, X-2, X-3, X-4. [pmid: 15139077].
3203 Snyder R, Turgay A, Aman M, et al. Effects of risperidone on conduct and disruptive behavior disorders in children with subaverage IQs. J Am Acad Child Adolesc Psychiatry. 09. 2002;41(9):1026-36. X-1, X-3. [pmid: 12218423].
3204 Soares DA, Vannest KJ, Harrison J. Computer aided self-monitoring to increase academic production and reduce self-injurious behavior in a child with autism. Behavioral Interventions. 07. 2009;24(3):171-183. X-1, X-3.
3205 Soden SE, Lowry JA, Garrison CB, et al. 24-hour provoked urine excretion test for heavy metals in children with autism and typically developing controls, a pilot study. Clin Toxicol (Phila). 06–08. 2007;45(5):476-81. X-4. [pmid: 17503250].
3206 Soenksen D, Alper S. Teaching a Young Child to Appropriately Gain Attention of Peers Using a Social Story Intervention. Focus on Autism and Other Developmental Disabilities. Spr. 2006;21(1):36-44. X-3.
3207 Sokhadze EM, El-Baz A, Baruth J, et al. Effects of Low Frequency Repetitive Transcranial Magnetic Stimulation (rTMS) on Gamma Frequency Oscillations and Event-Related Potentials during Processing of Illusory Figures in Autism. Journal of Autism and Developmental Disorders. 04. 2009;39(4):619-634. X-1, X-3. [pmid: 19030976].
3208 Sokol DK, Dunn DW, Edwards-Brown M, et al. Hydrogen proton magnetic resonance spectroscopy in autism: Preliminary evidence of elevated choline/creatine ratio. Journal of Child Neurology. 04. 2002;17(4):245-249. X-4. [pmid: 12088077].
3209 Sokolski KN, Chicz-Demet A, Demet EM. Case Report. Selective Serotonin Reuptake Inhibitor-Related Extrapyramidal Symptoms in Autistic Children: A Case Series. Journal of Child and Adolescent Psychopharmacology. Spr. 2004;14(1):143-147. X-3, X-4. [pmid: 15142402].
3210 Solish A, Perry A. Parents’ Involvement in Their Children’s Behavioral Intervention Programs: Parent and Therapist Perspectives. Research in Autism Spectrum Disorders. 10. 2008;2(4):728-738. X-1, X-4.
3211 Solomons S. Using Aromatherapy Massage to Increase Shared Attention Behaviours in Children with Autistic Spectrum Disorders and Severe Learning Difficulties. British Journal of Special Education. 09. 2005;32(3):127-137. X-3.
3212 Son SH, Sigafoos J, O’Reilly M, et al. Comparing two types of augmentative and alternative communication systems for children with autism. Pediatr Rehabil. 10–12. 2006;9(4):389-95. X-3. [pmid: 17111565].
3213 Soorya L, Kiarashi J, Hollander E. Psychopharmacologic interventions for repetitive behaviors in autism spectrum disorders. Child Adolesc Psychiatr Clin N Am. 10. 2008;17(4):753-71. viii. X-1, X-2, X-3, X-4. [pmid: 18775368].
3214 Soper HV, Elliott RO Jr, Rejzer AA, et al. Effects of fenfluramine on neuropsychological and communicative functioning in treatment-refractory schizophrenic patients. J Clin Psychopharmacol. 06. 1990;10(3):168-75. X-1, X-3, X-4, X-10. [pmid: 2198295].
3215 Soshensky R. Developing a guitar-based approach in Nordoff-Robbins music therapy. Music Therapy Perspectives. 2005;23(2):111-117. X-1, X-2,X-3, X-4.
3216 Sourander A, Ellila H, Valimaki M, et al. Use of holding, restraints, seclusion and time-out in child and adolescent psychiatric in-patient treatment. Eur Child Adolesc Psychiatry. 08. 2002;11(4):162-7. X-4. [pmid: 12444425].
3217 Sourander A, Helenius H, Piha J. Outcome of short-term child psychiatric hospitalization: teacher evaluation at 5-month and 12-month follow-up. Eur Child Adolesc Psychiatry. 12. 1996;5(4):204-11. X-10. [pmid: 8989559].
3218 Soutor TA, Houlihan D, Young A. An examination of response covariation on the behavioral treatment of identical twin boys with multiple behavioral disorders. Behavioral Interventions. 07. 1994;9(3):141-155. X-3, X-10.
3219 Sovner R. The use of valproate in the treatment of mentally retarded persons with typical and atypical bipolar disorders. Journal of Clinical Psychiatry. Special Issue: Emerging perspectives on valproate in affective disorders. 03. 1989;50(Suppl):40-43. X-1, X-3, X-10.
3220 Sowden H, Perkins M, Clegg J. The co-development of speech and gesture in children with autism. Clin Linguist Phon. 10–11. 2008;22(10–11):804-13. X-3. [pmid: 18608250].
3221 Spanarello S, Beoni AM, Mina G, et al. Analysis of differential clinical profiles of different antipsychotic molecules in the first psychotic episode: a retrospective study. Encephale. 11–12. 2005;31(6 Pt 1):692-7. X-1, X-3, X-4. [pmid: 16462688].
3222 Sparrow SS, Rescorla LA, Provence S, et al. Follow-up of “atypical” children--a brief report. J Am Acad Child Psychiatry. 03. 1986;25(2):181-5. X-10. [pmid: 3700905].
3223 Speers T, Lewis J. Journalists and jabs: media coverage of the MMR vaccine. Commun Med. 2004;1(2):171-81. X-1, X-3, X-4. [pmid: 16808699].
3224 Spencer EK, Alpert M, Pouget ER. Scales for the assessment of neuroleptic response in schizophrenic children: specific measures derived from the CPRS. Psychopharmacol Bull. 1994;30(2):199-202. X-4, X-10. [pmid: 7831455].
3225 Spencer KC, Turkett A, Vaughan R, et al. School-based practice patterns: a survey of occupational therapists in Colorado. Am J Occup Ther. 01–02. 2006;60(1):81-91. X-1, X-4. [pmid: 16541987].
3226 Spencer TD, Petersen DB, Gillam SL. Picture Exchange Communication System (PECS) or Sign Language: An Evidence-Based Decision-Making Example. TEACHING Exceptional Children. 11–12. 2008;41(2):40-47. X-1, X-2, X-3, X-4.
3227 Spencer VG, Simpson CG, Lynch SA. Using Social Stories to Increase Positive Behaviors for Children with Autism Spectrum Disorders. Intervention in School and Clinic. 2008;44(1):58-61. X-1, X-2, X-3, X-4.
3228 Spensley S. Cognitive deficit, mindlessness and psychotic depression: Observations of a “born loser.”. Journal of Child Psychotherapy. 1985;11(1):33-50. X-1, X-3, X-4, X-10.
3229 Spensley S. Mentally ill or mentally handicapped? A longitudinal study of severe learning disorder. Psychoanalytic Psychotherapy. 1985;1(3):55-70. X-1, X-3, X-4, X-10.
3230 Spero MH. The emancipation of time from autistic encapsulation: a study in the use of countertransference. Am J Psychoanal. 06. 1998;58(2):187-209. X-10. [pmid: 9648643].
3231 Sponheim E, Oftedal G, Helverschou SB. Multiple doses of secretin in the treatment of autism: a controlled study. Acta Paediatr. 2002;91(5):540-5. X-3. [pmid: 12113323].
3232 Sprafkin J, Volpe RJ, Gadow KD, et al. A DSM-IV-referenced screening instrument for preschool children: the Early Childhood Inventory-4. J Am Acad Child Adolesc Psychiatry. 05. 2002;41(5):604-12. X-4. [pmid: 12014793].
3233 Sprague JR, Horner RH. Covariation within functional response classes: Implications for treatment of severe problem behavior. Journal of Applied Behavior Analysis. Fal. 1992;25(3):735-745. X-3, X-10. [pmid: 1429324].
3234 Spreckley M, Boyd R. Efficacy of Applied Behavioral Intervention in Preschool Children with Autism for Improving Cognitive, Language, and Adaptive Behavior: A Systematic Review and Meta-analysis. J Pediatr. 2008. 10. 22. X-2.
3235 Srinath S, Chowdhury J, Bhide AV, et al. Descriptive study of infantile autism. NIMHANS Journal. 01. 1989;7(1):77-81. X-10.
3236 St John R. Transference and countertransference contributions toward understanding the phenomenon of institutionalization of schizophrenic patients. J Am Acad Psychoanal. Spring. 2001;29(1):17-32. X-1, X-2, X-3, X-4. [pmid: 11490675].
3237 Stagnitti K, Raison P, Ryan P. Sensory defensiveness syndrome: A paediatric perspective and case study. Australian Occupational Therapy Journal. 12. 1999;46(4):175-187. X-10.
3238 Stahmer AC. Teaching symbolic play skills to children with autism using pivotal response training. J Autism Dev Disord. 04. 1995;25(2):123-41. X-3, X-10. [pmid: 7559281].
3239 Stahmer AC. The basic structure of community early intervention programs for children with autism: provider descriptions. J Autism Dev Disord. 08. 2007;37(7):1344-54. X-1, X-4. [pmid: 17086438].
3240 Stahmer AC, Aarons GA. Attitudes toward adoption of evidence-based practices: A comparison of autism early intervention providers and childrenâ€™s mental health providers. Psychological Services. 2009;6(3):9. X-1, X-3, X-4.
3241 Stahmer AC, Carter C, Baker M, et al. Parent Perspectives on Their Toddlers’ Development: Comparison of Regular and Inclusion Childcare. Early Child Development and Care. 10. 2003;173(5):477-488. X-1, X-4.
3242 Stahmer AC, Collings NM, Palinkas LA. Early Intervention Practices for Children With Autism: Descriptions From Community Providers. Focus on Autism and Other Developmental Disabilities. Sum. 2005;20(2):66-79. X-1, X-3, X-4. [pmid: 16467905].
3243 Stahmer AC, Schreibman L. Teaching children with autism appropriate play in unsupervised environments using a self-management treatment package. J Appl Behav Anal. Summer. 1992;25(2):447-59. X-3, X-10. [pmid: 1634432].
3244 Stalhammar J, Bergman U, Boman K, et al. Metabolic control in diabetic subjects in three Swedish areas with high, medium, and low sales of antidiabetic drugs. Diabetes Care. 01. 1991;14(1):12-9. X-1, X-4, X-10. [pmid: 1899368].
3245 Standen PJ, Brown DJ. Virtual Reality in the Rehabilitation of People with Intellectual Disabilities: Review. CyberPsychology & Behavior. Special Issue: Use of Virtual Environments in Training and Rehabilitation: International Perspectives. 06. 2005;8(3):272-282. X-1, X-2, X-3, X-4.
3246 Starkova L, Wiedermann J. Our experience with incisive neuroleptic drugs in child psychiatry. Acta Univ Palacki Olomuc Fac Med. 1991;131:213-7. X-10. [pmid: 1687949].
3247 Stavrakaki C, Antochi R, Emery PC. Olanzapine in the treatment of pervasive developmental disorders: a case series analysis. J Psychiatry Neurosci. 01. 2004;29(1):57-60. X-1, X-3. [pmid: 14719051].
3248 Stavropoulos NE, Kim A, Nseyo UU, et al. Hypericum perforatum L. extract - novel photosensitizer against human bladder cancer cells. J Photochem Photobiol B. 07. 3. 2006;84(1):64-9. X-1, X-3, X-4. [pmid: 16540336].
3249 Steege MW, Mace FC, Perry L, et al. Applied Behavior Analysis: Beyond Discrete Trial Teaching. Psychology in the Schools. 01. 2007;44(1):91-99. X-1, X-2, X-3, X-4.
3250 Stefanatou A. Use of drawings in children with pervasive developmental disorder during hospitalization: a developmental perspective. J Child Health Care. 12. 2008;12(4):268-83. X-4. [pmid: 19052186].
3251 Stehr-Green P, Tull P, Stellfeld M, et al. Autism and thimerosal-containing vaccines: lack of consistent evidence for an association. Am J Prev Med. 08. 2003;25(2):101-6. X-4. [pmid: 12880876].
3252 Stein D, Ring A, Shulman C, et al. Brief report: Children with autism as they grow up--description of adult inpatients with severe autism. J Autism Dev Disord. 06. 2001;31(3):355-60. X-1, X-3, X-4. [pmid: 11518489].
3253 Stein MT, Faber S, Berger SP, et al. International adoption: a four-year-old child with unusual behaviors adopted at six months of age. J Dev Behav Pediatr. 10. 2004;25(5 Suppl):S26-32. X-1, X-2, X-3, X-4. [pmid: 15502529].
3254 Stein SJ, McNairn C. The changing nature of diagnosis in an inpatient service over 20 years. J Abnorm Child Psychol. 09. 1983;11(3):443-61. X-4, X-10. [pmid: 6643862].
3255 Steinborn M, Knapp TJ. Teaching an autistic child pedestrian skills. Journal of Behavior Therapy and Experimental Psychiatry. 12. 1982;13(4):347-351. X-10. [pmid: 7166609].
3256 Steingard R, Biederman J. Lithium responsive manic-like symptoms in two individuals with autism and mental retardation. Journal of the American Academy of Child & Adolescent Psychiatry. 11. 1987;26(6):932-935. X-3, X-10. [pmid: 2892825].
3257 Stel M, van den Heuvel C, Smeets RC. Facial feedback mechanisms in autistic spectrum disorders. J Autism Dev Disord. 08. 2008;38(7):1250-8. X-4. [pmid: 18293075].
3258 Stengel BE. Developmental group therapy with autistic and other severely psychosocially handicapped adolescents. Int J Group Psychother. 07. 1987;37(3):417-31. X-1, X-10. [pmid: 3667016].
3259 Stephens CE. Spontaneous imitation by children with autism during a repetitive musical play routine. Autism. 11. 2008;12(6):645-71. X-3. [pmid: 19005033].
3260 Stephenson J, Carter M. The Use of Weighted Vests with Children with Autism Spectrum Disorders and Other Disabilities. Journal of Autism and Developmental Disorders. 01. 2009;39(1):105-114. X-1, X-2, X-3. [pmid: 18592366].
3261 Stephenson J, Wheldall K. Miracles Take a Little Longer: Science, Commercialisation, Cures and the Dore Program. Australasian Journal of Special Education. 04. 2008;32(1):67-82. X-1, X-2, X-3, X-4.
3262 Stephenson MB. Famotidine (Pepcid) and Autistic Spectrum Disorders: A Reason for Optimism, or for Heartburn?. The Scientific Review of Mental Health Practice. Fall-Win. 2002;1(2):184-188. X-1, X-2, X-3, X-4.
3263 Sterling-Turner HE, Jordan SS. Interventions Addressing Transition Difficulties for Individuals with Autism. Psychology in the Schools. 09. 2007;44(7):681-690. X-1, X-2, X-3, X-4.
3264 Stern LM, Walker MK, Sawyer MG, et al. A controlled crossover trial of fenfluramine in autism. J Child Psychol Psychiatry. 05. 1990;31(4):569-85. X-10. [pmid: 2195054].
3265 Stevens S, Gruzelier J. Electrodermal activity to auditory stimuli in autistic, retarded, and normal children. J Autism Dev Disord. 09. 1984;14(3):245-60. X-4, X-10. [pmid: 6480545].
3266 Stevenson CL, Krantz PJ, McClannahan LE. Social interaction skills for children with autism: A script-fading procedure for nonreaders. Behavioral Interventions. 01–03. 2000;15(1):1-20. X-3.
3267 Stewart AM. When vaccine injury claims go to court. N Engl J Med. 06. 11. 2009;360(24):2498-500. X-1, X-2, X-3, X-4. [pmid: 19516030].
3268 Stewart SH, Latham PK, Miller PM, et al. Blood pressure reduction during treatment for alcohol dependence: results from the Combining Medications and Behavioral Interventions for Alcoholism (COMBINE) study. Addiction. 10. 2008;103(10):1622-8. X-1, X-3, X-4. [pmid: 18821872].
3269 Stichter JP, Randolph J, Gage N, et al. A Review of Recommended Social Competency Programs for Students with Autism Spectrum Disorders. Exceptionality. 11. 2007;15(4):219-232. X-1, X-2, X-3.
3270 Stichter JP, Randolph JK, Kay D, et al. The use of structural analysis to develop antecedent-based interventions for students with autism. J Autism Dev Disord. 06. 2009;39(6):883-96. X-1, X-3. [pmid: 19191017].
3271 Stiebel D. Promoting augmentive communication during daily routines: A parent problem-solving intervention. Journal of Positive Behavior Interventions. Sum. 1999;1(3):159-169. X-10.
3272 Stiegler LN. Discovering Communicative Competencies in a Nonspeaking Child with Autism. Language, Speech, and Hearing Services in Schools. 10. 2007;38(4):400-413. X-1, X-3, X-4.
3273 Stigler KA, Diener JT, Kohn AE, et al. Aripiprazole in pervasive developmental disorder not otherwise specified and Asperger’s disorder: a 14-week, prospective, open-label study. J Child Adolesc Psychopharmacol. 06. 2009;19(3):265-74. X-3. [pmid: 19519261].
3274 Stigler KA, Posey DJ, McDougle CJ. Aripiprazole for Maladaptive Behavior in Pervasive Developmental Disorders. Journal of Child and Adolescent Psychopharmacology. Fal. 2004;14(3):455-463. X-3. [pmid: 15650503].
3275 Stigler KA, Potenza MN, Posey DJ, et al. Weight gain associated with atypical antipsychotic use in children and adolescents: prevalence, clinical relevance, and management. Paediatr Drugs. 2004;6(1):33-44. X-1, X-2, X-3. [pmid: 14969568].
3276 Stiver RL, Dobbins JP. Treatment of atypical anorexia nervosa in the public school: an autistic girl. J Autism Dev Disord. 03. 1980;10(1):67-73. X-3, X-10. [pmid: 6927680].
3277 Stoddart KP. Adolescents with Asperger syndrome: Three case studies of individual and family therapy. Autism. 09. 1999;3(3):255-271. X-1, X-3, X-4, X-10.
3278 Stoelb M, Yarnal R, Miles J, et al. Predicting Responsiveness to Treatment of Children with Autism: A Retrospective Study of the Importance of Physical Dysmorphology. Focus on Autism and Other Developmental Disabilities. Sum. 2004;19(2):66-77. X-6.
3279 Stone VE, Baron-Cohen S, Knight RT. Frontal lobe contributions to theory of mind. J Cogn Neurosci. 09. 1998;10(5):640-56. X-4, X-10. [pmid: 9802997].
3280 Stone WL, Caro-Martinez LM. Naturalistic observations of spontaneous communication in autistic children. J Autism Dev Disord. 12. 1990;20(4):437-53. X-4, X-10. [pmid: 2279967].
3281 Stone WL, Lemanek KL, Fishel PT, et al. Play and Imitation Skills in the Diagnosis of Autism in Young-Children. Pediatrics. 1990;86(2):267-272. X-10. [pmid: 2371101].
3282 Stone WL, Ousley OY, Yoder PJ, et al. Nonverbal communication in two- and three-year-old children with autism. J Autism Dev Disord. 12. 1997;27(6):677-96. X-4, X-10. [pmid: 9455728].
3283 Stone WL, Rosenbaum JL. A comparison of teacher and parent views of autism. J Autism Dev Disord. 09. 1988;18(3):403-14. X-1, X-4, X-10. [pmid: 3170456].
3284 Stone WL, Yoder PJ. Predicting spoken language level in children with autism spectrum disorders. Autism. 12. 2001;5(4):341-61. X-4. [pmid: 11777253].
3285 Strain PS. Identification of social skill curriculum targets for severely handicapped children in mainstream preschools. Appl Res Ment Retard. 1983;4(4):369-82. X-4, X-10. [pmid: 6670873].
3286 Strain PS, Hoyson M. The need for longitudinal, intensive social skill intervention: LEAP follow-up outcomes for children with autism. Topics in Early Childhood Special Education. Special Issue: Early childhood special education in a new century: Voices from the past, visions for our future part 2. Sum. 2000;20(2):116-122. X-3.
3287 Strain PS, Kohler F. Peer-mediated social intervention for young children with autism. Semin Speech Lang. 1998;19(4):391-404. quiz 404–5; 424. X-2, X-10. [pmid: 9857394].
3288 Strain PS, Kohler FW, Storey K, et al. Teaching preschoolers with autism to self-monitor their social interactions: An analysis of results in home and school settings. Journal of Emotional and Behavioral Disorders. 04. 1994;2(2):78-88. X-10.
3289 Strambi M, Longini M, Hayek J, et al. Magnesium profile in autism. Biol Trace Elem Res. 02. 2006;109(2):97-104. X-4. [pmid: 16443999].
3290 Strauss DJ, Day SM, Shavelle RM, et al. Remote symptomatic epilepsy: does seizure severity increase mortality?. Neurology. 02. 11. 2003;60(3):395-9. X-1, X-3, X-4. [pmid: 12578917].
3291 Strauss WL, Unis AS, Cowan C, et al. Fluorine magnetic resonance spectroscopy measurement of brain fluvoxamine and fluoxetine in pediatric patients treated for pervasive developmental disorders. Am J Psychiatry. 05. 2002;159(5):755-60. X-1, X-4. [pmid: 11986128].
3292 Strayhorn JM. The vitamin and mineral mystery. J Am Acad Child Adolesc Psychiatry. 11–12. 1994;33(9):1346-7. X-10. [pmid: 7995802].
3293 Strayhorn JM, Rapp N, Donina W, et al. Randomized trial of methylphenidate for an autistic child. Journal of the American Academy of Child & Adolescent Psychiatry. 03. 1988;27(2):244-247. X-3, X-10. [pmid: 3360731].
3294 Stribling P, Rae J, Dickerson P. Using Conversation Analysis to Explore the Recurrence of a Topic in the Talk of a Boy with an Autism Spectrum Disorder. Clinical Linguistics & Phonetics. 08. 2009;23(8):555-582. X-3, X-4. [pmid: 19669991].
3295 Stringer MD. Informed consent and choice in cholecystectomy. Pediatr Surg Int. 10. 2004;20(10):741-3. X-4. [pmid: 15490193].
3296 Stromer R, Mackay HA, Remington B. Naming, the formation of stimulus classes, and applied behavior analysis. J Appl Behav Anal. Fall. 1996;29(3):409-31. X-1, X-2, X-3, X-4, X-10. [pmid: 8810064].
3297 Stubbs EG, Budden SS, Burger DR, et al. Transfer factor immunotherapy of an autistic child with congenital cytomegalovirus. J Autism Dev Disord. 12. 1980;10(4):451-8. X-1, X-2, X-3, X-4, X-10. [pmid: 6100889].
3298 Stubbs EG, Budden SS, Jackson RH, et al. Effects of fenfluramine on eight outpatients with the syndrome of autism. Dev Med Child Neurol. 04. 1986;28(2):229-35. X-3, X-10. [pmid: 3709993].
3299 Stuhec V, Gisel EG. Compliance with administration procedures of tests for children with pervasive developmental disorders: does it exist?. Can J Occup Ther. 02. 2003;70(1):33-41. X-1, X-3, X-4. [pmid: 12619397].
3300 Suedfeld P, Schwartz G. Restricted environmental stimulation therapy (REST) as a treatment for autistic children. J Dev Behav Pediatr. 09. 1983;4(3):196-201. X-10. [pmid: 6630534].
3301 Sugai G, White WJ. Effects of using object self-stimulation as a reinforcer on the prevocational work rates of an autistic child. Journal of Autism and Developmental Disorders. 12. 1986;16(4):459-471. X-1, X-3, X-4, X-10. [pmid: 3804959].
3302 Sugano C, Hatori H, Inoue M, et al. Training a student with autism in purchasing skills: Generalization and maintenance in daily life. Japanese Journal of Special Education. 11. 1995;33(3):33-38. X-1, X-3, X-10.
3303 Sugarman SD. Cases in vaccine court--legal battles over vaccines and autism. N Engl J Med. 09. 27. 2007;357(13):1275-7. X-1, X-2, X-3, X-4. [pmid: 17898095].
3304 Sugie Y, Sugie H, Fukuda T, et al. Clinical efficacy of fluvoxamine and functional polymorphism in a serotonin transporter gene on childhood autism. J Autism Dev Disord. 06. 2005;35(3):377-85. X-3. [pmid: 16119478].
3305 Sugimoto H, Okochi O, Hirota M, et al. Early detection of liver failure after hepatectomy by indocyanine green elimination rate measured by pulse dye-densitometry. J Hepatobiliary Pancreat Surg. 2006;13(6):543-8. X-1, X-4. [pmid: 17139429].
3306 Sugiyama T, Takahasi O. Jiheishou to shurou. / Employment of the autistics. Japanese Journal of Child and Adolescent Psychiatry. 12–02. 1996;37(1):19-25. X-1, X-3, X-4, X-10.
3307 Sukhodolsky DG, Scahill L, Gadow KD, et al. Parent-rated anxiety symptoms in children with pervasive developmental disorders: frequency and association with core autism symptoms and cognitive functioning. J Abnorm Child Psychol. 01. 2008;36(1):117-28. X-4. [pmid: 17674186].
3308 Sullivan M, Finelli J, Marvin A, et al. Response to Joint Attention in Toddlers at Risk for Autism Spectrum Disorder: A Prospective Study. Journal of Autism and Developmental Disorders. 01. 2007;37(1):37-48. X-4. [pmid: 17216332].
3309 Sullivan RC. What does deinstitutionalization mean for our children?. J Autism Dev Disord. 09. 1981;11(3):347-56. X-10. [pmid: 7052811].
3310 Sulzer-Azaroff B, Fleming R, Tupa M, et al. Choosing Objectives for a Distance Learning Behavioral Intervention in Autism Curriculum. Focus on Autism and Other Developmental Disabilities. 2008;23(1):29-36. X-1, X-3, X-4.
3311 Summers JA, Houlding CM, Reitzel J-AM. Behavior Management Services for Children with Autism/PDD: Program Description and Patterns of Referral. Focus on Autism and Other Developmental Disabilities. Sum. 2004;19(2):95-101. X-1, X-3, X-4.
3312 Sun QY, Rubinstein S, Breitbart H. MAP kinase activity is downregulated by phorbol ester during mouse oocyte maturation and egg activation in vitro. Mol Reprod Dev. 03. 1999;52(3):310-8. X-1, X-2, X-3, X-4, X-10. [pmid: 10206663].
3313 Sundberg ML, Endicott K, Eigenheer P. Using intraverbal prompts to establish tacts for children with autism. Analysis of Verbal Behavior. 2000;17:89-104. X-3.
3314 Sundberg ML, Michael J. The benefits of Skinner’s analysis of verbal behavior for children with autism. Behav Modif. 10. 2001;25(5):698-724. X-1, X-2, X-3, X-4. [pmid: 11573336].
3315 Sutera S, Pandey J, Esser EL, et al. Predictors of optimal outcome in toddlers diagnosed with autism spectrum disorders. J Autism Dev Disord. 01. 2007;37(1):98-107. X-1, X-4. [pmid: 17206522].
3316 Sutton SK, Burnette CP, Mundy PC, et al. Resting cortical brain activity and social behavior in higher functioning children with autism. J Child Psychol Psychiatry. 02. 2005;46(2):211-22. X-4. [pmid: 15679529].
3317 Suwa S, Naruse H, Ohura T, et al. Influence of pimozide on hypothalamo-pituitary function in children with behavioral disorders. Psychoneuroendocrinology. 1984;9(1):37-44. X-10. [pmid: 6429690].
3318 Suzumura K. How an autistic boy speaks about his own past experiences. Japanese Journal of Special Education. 1984;22(2):21. X-3, X-10.
3319 Sverd J, Dubey DR, Schweitzer R, et al. Pervasive developmental disorders among children and adolescents attending psychiatric day treatment. Psychiatr Serv. 11. 2003;54(11):1519-25. X-4. [pmid: 14600312].
3320 Swaggart B, Gagnon E, Bock SJ, et al. Using social stories to teach social and behavioral skills to children with autism. Focus on Autistic Behavior. 04. 1995;10(1):1-16. X-3, X-10.
3321 Swaim KF, Morgan SB. Children’s attitudes and behavioral intentions toward a peer with autistic behaviors: does a brief educational intervention have an effect?. J Autism Dev Disord. 04. 2001;31(2):195-205. X-1, X-3, X-4. [pmid: 11450818].
3322 Swartzwelder HS, Holahan W, Myers RD. Antagonism by d-amphetamine of trimethyltin-induced hyperactivity evidence toward an animal model of hyperkinetic behavior. Neuropharmacology. 09. 1983;22(9):1049-54. X-1, X-3, X-4, X-10. [pmid: 6685232].
3323 Sweeney HM, LeBlanc JM. Effects of task size on work-related and aberrant behaviors of youths with autism and mental retardation. Res Dev Disabil. 03–04. 1995;16(2):97-115. X-10. [pmid: 7792411].
3324 Sweeney-Kerwin EJ, Carbone VJ, O’Brien L, et al. Transferring control of the mand to the motivating operation in children with autism. Analysis of Verbal Behavior. 2007;23:89-102. X-3.
3325 Sweet MA, Appelbaum MI. Is home visiting an effective strategy? A meta-analytic review of home visiting programs for families with young children. Child Dev. 09–10. 2004;75(5):1435-56. X-1, X-3, X-4. [pmid: 15369524].
3326 Swettenham J. Can children with autism be taught to understand false belief using computers?. J Child Psychol Psychiatry. 02. 1996;37(2):157-65. X-10. [pmid: 8682895].
3327 Swiezy NB, Summers J. Parents’ perceptions of the use of medication with children who are autistic. Journal of Developmental and Physical Disabilities. 12. 1996;8(4):407-413. X-10.
3328 Sydenstricker T. Musicoterapia: uma alternativa para psicÃ^3^ticos. / Music therapy: An alternative for psychosis treatment. Jornal Brasileiro de Psiquiatria. 11–12. 1991;40(10):509-513. X-3, X-10.
3329 Symes MD, Remington B, Brown T, et al. Early intensive behavioral intervention for children with autism: therapists’ perspectives on achieving procedural fidelity. Res Dev Disabil. 01–02. 2006;27(1):30-42. X-1, X-4. [pmid: 15935615].
3330 Symon JB. Expanding Interventions for Children with Autism: Parents as Trainers. Journal of Positive Behavior Interventions. 2005;7(3):159-173. X-3.
3331 Symons F, Davis M. Instructional conditions and stereotyped behavior: The function of prompts. Journal of Behavior Therapy and Experimental Psychiatry. 12. 1994;25(4):317-324. X-1, X-3, X-10. [pmid: 7706509].
3332 Symons FJ, Fox ND, Thompson T. Functional communication training and naltrexone treatment of self-injurious behaviour: An experimental case report. Journal of Applied Research in Intellectual Disabilities. 1998;11(3):273-292. X-3, X-10.
3333 Symons FJ, Hoch J, Dahl NA, et al. Sequential and matching analyses of self-injurious behavior a case of overmatching in the natural environment. J Appl Behav Anal. Summer. 2003;36(2):267-70. X-4. [pmid: 12858993].
3334 Symons FJ, Thompson A, Rodriguez MC. Self-Injurious Behavior and the Efficacy of Naltrexone Treatment: A Quantitative Synthesis. Mental Retardation and Developmental Disabilities Research Reviews. 2004;10(3):193-200. X-2, X-3. [pmid: 15611982].
3335 Szabo CP, Aber D. Asperger’s syndrome: A valid DSM IV diagnostic entitity? A case report. Southern African Journal of Child & Adolescent Psychiatry. 1992;4(1):3-7. X-1, X-3, X-4, X-10.
3336 Szabo CP, Bracken C. Imipramine and Asperger’s. Journal of the American Academy of Child & Adolescent Psychiatry. 03–04. 1994;33(3):431-432. X-1, X-3, X-10.
3337 Szapacs C. Applied Behavior Analysis. Teaching Elementary Physical Education. 11. 2006;17(6):12-15. X-1, X-2, X-3, X-4.
3338 Szatmari P, Archer L, Fisman S, et al. Parent and teacher agreement in the assessment of pervasive developmental disorders. J Autism Dev Disord. 12. 1994;24(6):703-17. X-4, X-10. [pmid: 7844095].
3339 Szatmari P, Archer L, Fisman S, et al. Asperger’s syndrome and autism: differences in behavior, cognition, and adaptive functioning. J Am Acad Child Adolesc Psychiatry. 12. 1995;34(12):1662-71. X-4, X-10. [pmid: 8543538].
3340 Szatmari P, Streiner DL. The effect of selection criteria on outcome studies of children with pervasive developmental disorders (PDD). Eur Child Adolesc Psychiatry. 12. 1996;5(4):179-84. X-10. [pmid: 8989556].
3341 Szekely GA, Caplan R, Rotman A. Platelet dopamine uptake in autistic and other psychotic children. Inhibition by imipramine. Prog Neuropsychopharmacol. 1980;4(2):215-8. X-10. [pmid: 7403355].
3342 Szempruch J, Jacobson JW. Evaluating facilitated communications of people with developmental disabilities. Res Dev Disabil. 07–08. 1993;14(4):253-64. X-10. [pmid: 8210603].
3343 Szigethy E, Wiznitzer M, Branicky LA, et al. Risperidone-induced hepatotoxicity in children and adolescents? A chart review study. Journal of Child and Adolescent Psychopharmacology. 1999;9(2):93-98. X-10. [pmid: 10461819].
3344 Tada M, Kato M. Acquisition of Mands Through a Behavior Chain Interruption Strategy: Task Preference and Occurrence of Verbal Requests by a Child With Autistic Spectrum Disorders. Japanese Journal of Special Education. 03. 2005;42(6):513-524. X-3.
3345 Tager-Flusberg H. Brief report: current theory and research on language and communication in autism. J Autism Dev Disord. 04. 1996;26(2):169-72. X-10. [pmid: 8744479].
3346 Tager-Flusberg H, Calkins S. Does imitation facilitate the acquisition of grammar? Evidence from a study of autistic, Down’s syndrome and normal children. J Child Lang. 10. 1990;17(3):591-606. X-3, X-10. [pmid: 2148571].
3347 Tager-Flusberg H, Rogers S, Cooper J, et al. Defining Spoken Language Benchmarks and Selecting Measures of Expressive Language Development for Young Children with Autism Spectrum Disorders. Journal of Speech, Language, and Hearing Research. 06. 2009;52(3):643-652. X-1, X-2, X-4.
3348 Taira M, Takase M, Sasaki H. Sleep disorder in children with autism. Psychiatry Clin Neurosci. 04. 1998;52(2):182-3. X-4, X-10. [pmid: 9628139].
3349 Takahashi H, Arai S, Tanaka-Taya K, et al. Autism and infection/immunization episodes in Japan. Jpn J Infect Dis. 04. 2001;54(2):78-9. X-1, X-2, X-3, X-4. [pmid: 11427748].
3350 Takahashi H, Suzumura S, Shirakizawa F, et al. An epidemiological study on Japanese autism concerning routine childhood immunization history. Jpn J Infect Dis. 06. 2003;56(3):114-7. X-4. [pmid: 12944678].
3351 Takase M, Taira M, Sasaki H. Sleep-wake rhythm of autistic children. Psychiatry Clin Neurosci. 04. 1998;52(2):181-2. X-4, X-10. [pmid: 9628138].
3352 Takeuchi K, Kubota H, Yamamoto J-i. Intensive supervision for families conducting home-based behavioral treatment for children with autism in Malaysia. Japanese Journal of Special Education. 03. 2002;39(6):155-164. X-3.
3353 Tallal P, Merzenich M, Miller S, et al. Language learning impairment: integrating research and remediation. Scand J Psychol. 09. 1998;39(3):197-9. X-10. [pmid: 9800537].
3354 Tamanaha AC, Perissinoto J, Chiari BM. Development of autistic children based on maternal responses to the Autism Behavior Checklist. Pro Fono. 2008;20(3):165-70. X-4. [pmid: 18852963].
3355 Tammilmani V, Yee KK, Heng PW, et al. An evaluation of exogenous application of protoporphyrin IX and its dimethyl ester as a photodynamic diagnostic agent in poorly differentiated human nasopharyngeal carcinoma. Photochem Photobiol. 11–12. 2004;80(3):596-601. X-3, X-4. [pmid: 15323583].
3356 Tang JC, Kennedy CH, Koppekin A, et al. Functional analysis of stereotypical ear covering in a child with autism. J Appl Behav Anal. Spring. 2002;35(1):95-8. X-3, X-4. [pmid: 11936553].
3357 Tansy M. Test Reviews: Euler, B. L. (2007). “Emotional Disturbance Decision Tree”. Lutz, FL: Psychological Assessment Resources. Journal of Psychoeducational Assessment. 2009;27(1):68-78. X-1, X-2, X-3, X-4.
3358 Taras ME, Matson JL, Felps JN. Using independence training to teach independent living skills to children and young men with visual impairments. Behav Modif. 04. 1993;17(2):189-208. X-3, X-10. [pmid: 8471011].
3359 Taras ME, Matson JL, Leary C. Training social interpersonal skills in two autistic children. J Behav Ther Exp Psychiatry. 12. 1988;19(4):275-80. X-3, X-10. [pmid: 3235695].
3360 Tarbox J, Wallace MD, Tarbox RSF. Successful generalized parent training and failed schedule thinning of response blocking for automatically maintained object mouthing. Behavioral Interventions. 07–09. 2002;17(3):169-178. X-3.
3361 Tarbox RS, Wallace MD, Williams L. Assessment and treatment of elopement: a replication and extension. J Appl Behav Anal. Summer. 2003;36(2):239-44. X-1, X-3. [pmid: 12858987].
3362 Tarbox RSF, Ghezzi PM, Wilson G. The effects of token reinforcement on attending in a young child with autism. Behavioral Interventions. 07. 2006;21(3):155-164. X-3.
3363 Tardif C, Laine F, Rodriguez M, et al. Slowing down presentation of facial movements and vocal sounds enhances facial expression recognition and induces facial-vocal imitation in children with autism. J Autism Dev Disord. 09. 2007;37(8):1469-84. X-1, X-4. [pmid: 17029018].
3364 Tartaglia N, Davis S, Hench A, et al. A new look at XXYY syndrome: medical and psychological features. Am J Med Genet A. 06. 15. 2008;146A(12):1509-22. X-1, X-4. [pmid: 18481271].
3365 Taubman M, Brierley S, Wishner J, et al. The effectiveness of a group discrete trial instructional approach for preschoolers with developmental disabilities. Res Dev Disabil. 05–06. 2001;22(3):205-19. X-3. [pmid: 11380059].
3366 Taylor B, Lingam R, Simmons A, et al. Autism and MMR vaccination in North London; no causal relationship. Mol Psychiatry. 2002;7(Suppl 2):S7-8. X-1, X-2, X-3, X-4. [pmid: 12142932].
3367 Taylor B, Miller E, Lingam R, et al. Measles, mumps, and rubella vaccination and bowel problems or developmental regression in children with autism: population study. BMJ. 02. 16. 2002;324(7334):393-6. X-4. [pmid: 11850369].
3368 Taylor BA, Harris SL. Teaching children with autism to seek information: acquisition of novel information and generalization of responding. J Appl Behav Anal. Spring. 1995;28(1):3-14. X-3, X-10. [pmid: 7706148].
3369 Taylor BA, Hoch H. Teaching children with autism to respond to and initiate bids for joint attention. J Appl Behav Anal. Fall. 2008;41(3):377-91. X-3. [pmid: 18816976].
3370 Taylor BA, Hoch H, Potter B, et al. Manipulating establishing operations to promote initiations toward peers in children with autism. Res Dev Disabil. 07–08. 2005;26(4):385-92. X-3. [pmid: 15766630].
3371 Taylor BA, Hoch H, Weissman M. The analysis and treatment of vocal stereotypy in a child with autism. Behavioral Interventions. 11. 2005;20(4):239-253. X-3.
3372 Taylor BA, Levin L, Jasper S. Increasing play-related statements in children with autism toward their siblings: Effects of video modeling. Journal of Developmental and Physical Disabilities. 09. 1999;11(3):253-264. X-10.
3373 Taylor DC, Neville BG, Cross JH. Autistic spectrum disorders in childhood epilepsy surgery candidates. Eur Child Adolesc Psychiatry. 09. 1999;8(3):189-92. X-4, X-10. [pmid: 10550700].
3374 Taylor DV, Hetrick WP, Neri CL, et al. Effect of naltrexone upon self-injurious behavior, learning and activity: A case study. Pharmacology, Biochemistry and Behavior. 09. 1991;40(1):79-82. X-1, X-3, X-10.
3375 Taylor E, Dopfner M, Sergeant J, et al. European clinical guidelines for hyperkinetic disorder -- first upgrade. Eur Child Adolesc Psychiatry. 2004;13(Suppl 1):I7-30. X-1, X-2, X-3, X-4. [pmid: 15322953].
3376 Taylor I, O’Reilly M, Lancioni G. An evaluation of an ongoing consultation model to train teachers to treat challenging behaviour. International Journal of Disability, Development and Education. 1996;43(3):203-218. X-3, X-10.
3377 Taylor JC, Carr EG. Severe problem behaviors related to social interaction. 1: Attention seeking and social avoidance. Behav Modif. 07. 1992;16(3):305-35. X-4, X-10. [pmid: 1385701].
3378 Taylor JC, Carr EG. Severe problem behaviors related to social interaction. 2: A systems analysis. Behav Modif. 07. 1992;16(3):336-71. X-4, X-10. [pmid: 1385702].
3379 Taylor JC, Ekdahl MM, Romanczyk RG, et al. Escape behavior in task situations: task versus social antecedents. J Autism Dev Disord. 06. 1994;24(3):331-44. X-3, X-4, X-10. [pmid: 8050986].
3380 Taylor JP, Colloby SJ, McKeith IG, et al. Cholinesterase inhibitor use does not significantly influence the ability of 123I-FP-CIT imaging to distinguish Alzheimer’s disease from dementia with Lewy bodies. J Neurol Neurosurg Psychiatry. 10. 2007;78(10):1069-71. X-1, X-4. [pmid: 17299017].
3381 Taylor S, Cipani E, Clardy A. A stimulus control technique for improving the efficacy of an established toilet training program. Journal of Behavior Therapy and Experimental Psychiatry. 06. 1994;25(2):155-160. X-3, X-10. [pmid: 7983227].
3382 Tecchio F, Benassi F, Zappasodi F, et al. Auditory sensory processing in autism: a magnetoencephalographic study. Biol Psychiatry. 09. 15. 2003;54(6):647-54. X-4. [pmid: 13129660].
3383 Teising M. Permeability and demarcation in the psychoanalytic process. Functions of the contact-barrier. Int J Psychoanal. 12. 2005;86(Pt 6):1627-44. X-1, X-2, X-3, X-4. [pmid: 16318941].
3384 Terai K, Munesue T, Hiratani M. Excessive water drinking behavior in autism. Brain Dev. 03. 1999;21(2):103-6. X-4, X-10. [pmid: 10206527].
3385 Terry M. Telemedicine and autism: researchers and clinicians are just starting to consider telemedicine applications for the diagnosis and treatment of autism. Telemed J E Health. 06. 2009;15(5):416-9. X-1, X-2, X-3, X-4. [pmid: 19548820].
3386 Tesink CM, Buitelaar JK, Petersson KM, et al. Neural correlates of pragmatic language comprehension in autism spectrum disorders. Brain. 07. 2009;132(Pt 7):1941-52. X-1, X-3, X-4. [pmid: 19423680].
3387 Tews L. Early Intervention for Children with Autism: Methodologies Critique. Developmental Disabilities Bulletin. 2007;35(1–2):148-168. X-1, X-2, X-3.
3388 Thakkar KN, Polli FE, Joseph RM, et al. Response monitoring, repetitive behaviour and anterior cingulate abnormalities in autism spectrum disorders (ASD). Brain. 09. 2008;131(Pt 9):2464-78. X-1, X-4. [pmid: 18550622].
3389 Thalayasingam S, Alexander RT, Singh I. The use of clozapine in adults with intellectual disability. J Intellect Disabil Res. 09. 2004;48(Pt 6):572-9. X-1, X-3, X-4. [pmid: 15312058].
3390 Tharpe AM, Fino-Szumski MS, Bess FH. Survey of hearing aid fitting practices for children with multiple impairments. Am J Audiol. 06. 2001;10(1):32-40. X-1, X-2, X-4. [pmid: 11501895].
3391 Thede LL, Coolidge FL. Psychological and Neurobehavioral Comparisons of Children with Asperger’s Disorder versus High-Functioning Autism. Journal of Autism and Developmental Disorders. 05. 2007;37(5):847-854. X-4. [pmid: 16977495].
3392 Thiemann KS, Goldstein H. Social stories, written text cues, and video feedback: effects on social communication of children with autism. J Appl Behav Anal. Winter. 2001;34(4):425-46. X-3. [pmid: 11800183].
3393 Thiemann KS, Goldstein H. Effects of Peer Training and Written Text Cueing on Social Communication of School-Age Children With Pervasive Developmental Disorder. Journal of Speech, Language, and Hearing Research. 02. 2004;47(1):126-144. X-3.
3394 Thiessen C, Fazzio D, Arnal L, et al. Evaluation of a self-instructional manual for conducting discrete-trials teaching with children with autism. Behav Modif. 05. 2009;33(3):360-73. X-3, X-4. [pmid: 19139527].
3395 Thomas AJ, Burn DJ, Rowan EN, et al. A comparison of the efficacy of donepezil in Parkinson’s disease with dementia and dementia with Lewy bodies. Int J Geriatr Psychiatry. 10. 2005;20(10):938-44. X-1, X-4. [pmid: 16163744].
3396 Thomas KC, Ellis AR, McLaurin C, et al. Access to care for autism-related services. J Autism Dev Disord. 11. 2007;37(10):1902-12. X-4. [pmid: 17372817].
3397 Thomas KC, Morrissey JP, McLaurin C. Use of autism-related services by families and children. J Autism Dev Disord. 05. 2007;37(5):818-29. X-4. [pmid: 17146709].
3398 Thomas N, Smith C. Developing Play Skills in Children with Autistic Spectrum Disorders. Educational Psychology in Practice. 09. 2004;20(3):195-206. X-3.
3399 Thompson AR, Beail N. The treatment of auto-erotic asphyxiation in a man with severe intellectual disabilities: The effectiveness of a behavioural and educational programme. Journal of Applied Research in Intellectual Disabilities. 2002;15(1):36-47. X-1, X-3.
3400 Thompson DF, Thompson GD. Naltrexone in the management of seizures associated with Rett syndrome. Drug Intell Clin Pharm. 11. 1987;21(11):874. X-10. [pmid: 3678057].
3401 Thompson RH, Iwata BA, Hanley GP, et al. The effects of extinction, noncontingent reinforcement and differential reinforcement of other behavior as control procedures. J Appl Behav Anal. Summer. 2003;36(2):221-38. X-1, X-2, X-3, X-4. [pmid: 12858986].
3402 Thompson T. Self-Awareness: Behavior Analysis and Neuroscience. Behavior Analyst. Fall. 2008;31(2):137-144. X-1, X-2, X-3, X-4.
3403 Thompson WW, Price C, Goodson B, et al. Early thimerosal exposure and neuropsychological outcomes at 7 to 10 years. N Engl J Med. 09. 27. 2007;357(13):1281-92. X-2, X-4. [pmid: 17898097].
3404 Thomson A, Maltezos S, Paliokosta E, et al. Risperidone for attention-deficit hyperactivity disorder in people with intellectual disabilities. Cochrane Database Syst Rev. 2009;(2):CD007011. X-2.
3405 Thorne A. Are you ready to give care to a child with autism?. Nursing. 05. 2007;37(5):59-61. X-1, X-2, X-3,X- 4.
3406 Thorp DM, Stahmer AC, Schreibman L. Effects of sociodramatic play training on children with autism. J Autism Dev Disord. 06. 1995;25(3):265-82. X-3, X-10. [pmid: 7559292].
3407 Thunberg G, Ahlsen E, Sandberg AD. Children with autistic spectrum disorders and speech-generating devices: communication in different activities at home. Clin Linguist Phon. 06. 2007;21(6):457-79. X-3. [pmid: 17516231].
3408 Thuresson K, FÃ¤rnstrand M. A follow-up of medical treatment of persons with psychiatric health problems and mental retardation. Nordic Journal of Psychiatry. 1999;53(2):127-130. X-1, X-3, X-10.
3409 Tiegerman E, Primavera L. Object manipulation: an interactional strategy with autistic children. J Autism Dev Disord. 12. 1981;11(4):427-38. X-3, X-10. [pmid: 7052817].
3410 Tiegerman E, Primavera LH. Imitating the autistic child: facilitating communicative gaze behavior. J Autism Dev Disord. 03. 1984;14(1):27-38. X-10. [pmid: 6706896].
3411 Tien K-C. Effectiveness of the Picture Exchange Communication System as a Functional Communication Intervention for Individuals with Autism Spectrum Disorders: A Practice-Based Research Synthesis. Education and Training in Developmental Disabilities. 03. 2008;43(1):61-76. X-1, X-2, X-3.
3412 Tierney E, Aman M, Stout D, et al. Parent satisfaction in a multi-site acute trail of risperidone in children with autism: A social validity study. Psychopharmacology. Special Issue: Pediatric psychopharmacology: Mood, anxiety and disruptive behavior/pervasive developmental disorders. 03. 2007;191(1):149-157. X-1, X-3, X-4.
3413 Tiger JH, Bouxsein KJ, Fisher WW. Treating excessively slow responding of a young man with Asperger syndrome using differential reinforcement of short response latencies. Journal of Applied Behavior Analysis. Fal. 2007;40(3):559-563. X-1, X-3. [pmid: 17970270].
3414 Tiger JH, Fisher WW, Bouxsein KJ. Therapist- and self-monitored DRO contingencies as a treatment for the self-injurious skin picking of a young man with Asperger syndrome. Journal of Applied Behavior Analysis. Sum. 2009;42(2):315-319. X-1, X-3. [pmid: 19949518].
3415 Tiger JH, Hanley GP, Heal NA. The effectiveness of and preschoolers’ p for variations of multiple-schedule arrangements. J Appl Behav Anal. Winter. 2006;39(4):475-88. X-3. [pmid: 17236348].
3416 Tilsen J, Russell S, Nylund D. Nimble And Courageous Acts: How Michael Became The Boss Of Himself. Journal of Systemic Therapies. Sum. 2005;24(2):29-42. X-3.
3417 Tincani M. Comparing the Picture Exchange Communication System and Sign Language Training for Children with Autism. Focus on Autism and Other Developmental Disabilities. 09. 2004;19(3):152-163. X-3.
3418 Tjus T, Heimann M, Nelson K. Reading acquisition by implementing a multimedia intervention strategy for fifty children with autism or other learning and communication disabilities. Journal of Cognitive and Behavioral Psychotherapies. 09. 2004;4(2):203-221. X-6.

## DATA PAGES MISSING

3419 Tjus T, Heimann M, Nelson KE. Gains in literacy through the use of a specially developed multimedia computer strategy. Autism. 06. 1998;2(2):139-156. X-10.
3420 Tobing LE, Glenwick DS. Relation of the childhood autism rating scale-parent version to diagnosis, stress, and age. Res Dev Disabil. 05–06. 2002;23(3):211-23. X-1, X-4. [pmid: 12102589].
3421 Toda Y, Mori K, Hashimoto T, et al. Administration of secretin for autism alters dopamine metabolism in the central nervous system. Brain Dev. 03. 2006;28(2):99-103. X-3. [pmid: 16168596].
3422 Todd RD. Fluoxetine in autism. American Journal of Psychiatry. 08. 1991;148(8):1089. X-3, X-10.
3423 Todd T, Reid G. Increasing Physical Activity in Individuals with Autism. Focus on Autism and Other Developmental Disabilities. Fall. 2006;21(3):167-176. X-3.
3424 Tolbert L, Haigler T, Waits MM, et al. Brief report: lack of response in an autistic population to a low dose clinical trial of pyridoxine plus magnesium. J Autism Dev Disord. 03. 1993;23(1):193-9. X-10. [pmid: 8463199].
3425 Tomporowski PD. Training an autistic client: The effect of brief restraint on disruptive behavior. Journal of Behavior Therapy and Experimental Psychiatry. 06. 1983;14(2):169-173. X-1, X-3, X-10. [pmid: 6619299].
3426 Tonge B, Brereton A, Kiomall M, et al. Effects on parental mental health of an education and skills training program for parents of young children with autism: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. 05. 2006;45(5):561-9. X-1, X-4. [pmid: 16670650].
3427 Torisky DM, Torisky CV, Kaplan S, et al. The NAC pilot project: A model for nutrition screening and intervention for developmentally disabled children with behavior disorders. Journal of Orthomolecular Medicine. 1993;8(1):25-42. X-10.
3428 Torrance J. Autism, Aggression, and Developing a Therapeutic Contract. American Journal of Dance Therapy. Fal. 2003;25(2):97-109. X-2, X-3.
3429 Toth K, Dawson G, Meltzoff AN, et al. Early Social, Imitation, Play, and Language Abilities of Young Non-Autistic Siblings of Children with Autism. Journal of Autism and Developmental Disorders. 01. 2007;37(1):145-157. X-1, X-4. [pmid: 17216560].
3430 Toth K, Munson J, Meltzoff AN, et al. Early Predictors of Communication Development in Young Children with Autism Spectrum Disorder: Joint Attention, Imitation, and Toy Play. Journal of Autism and Developmental Disorders. 11. 2006;36(8):993-1005. X-4. [pmid: 16845578].
3431 Towbin KE. Strategies for pharmacologic treatment of high functioning autism and Asperger syndrome. Child Adolesc Psychiatr Clin N Am. 01. 2003;12(1):23-45. X-1, X-2, X-3. [pmid: 12512397].
3432 Towle PO, Visintainer PF, O’Sullivan C, et al. Detecting Autism Spectrum Disorder from Early Intervention Charts: Methodology and Preliminary Findings. Journal of Autism and Developmental Disorders. 03. 2009;39(3):444-452. X-2, X-3, X-4. [pmid: 18791816].
3433 Toya K. The Dohsa method: A Japanese therapy for autistic children. Emotional & Behavioural Difficulties. 05. 2003;8(2):152-163. X-1, X-2, X-3.
3434 Trajkovski V, Petlichkovski A, Efinska-Mladenovska O, et al. Higher Plasma Concentration of Food-Specific Antibodies in Persons with Autistic Disorder in Comparison to Their Siblings. Focus on Autism and Other Developmental Disabilities. 2008;23(3):176-185. X-4.
3435 Trembath D, Balandin S, Togher L, et al. Peer-mediated teaching and augmentative and alternative communication for preschool-aged children with autism. J Intellect Dev Disabil. 06. 2009;34(2):173-86. X-3. [pmid: 19404838].
3436 Trepagnier CY, Sebrechts MM, Finkelmeyer A, et al. Simulating social interaction to address deficits of autistic spectrum disorder in children. Cyberpsychol Behav. 04. 2006;9(2):213-7. X-1, X-2, X-3, X-4. [pmid: 16640482].
3437 Troost PW, Althaus M, Lahuis BE, et al. Neuropsychological effects of risperidone in children with pervasive developmental disorders: a blinded discontinuation study. J Child Adolesc Psychopharmacol. 10. 2006;16(5):561-73. X-1. [pmid: 17069545].
3438 Troost PW, Lahuis BE, Hermans MH, et al. Prolactin release in children treated with risperidone: impact and role of CYP2D6 metabolism. J Clin Psychopharmacol. 02. 2007;27(1):52-7. X-3. [pmid: 17224713].
3439 Troost PW, Lahuis BE, Steenhuis MP, et al. Long-term effects of risperidone in children with autism spectrum disorders: a placebo discontinuation study. J Am Acad Child Adolesc Psychiatry. 11. 2005;44(11):1137-44. X-3. [pmid: 16239862].
3440 Troost PW, Steenhuis MP, Tuynman-Qua HG, et al. Atomoxetine for attention-deficit/hyperactivity disorder symptoms in children with pervasive developmental disorders: a pilot study. J Child Adolesc Psychopharmacol. 10. 2006;16(5):611-9. X-1. [pmid: 17069549].
3441 Trosclair-Lasserre NM, Lerman DC, Call NA, et al. Reinforcement magnitude: an evaluation of preference and reinforcer efficacy. J Appl Behav Anal. Summer. 2008;41(2):203-20. X-3. [pmid: 18595284].
3442 Troster H. Prevalence and functions of stereotyped behaviors in nonhandicapped children in residential care. J Abnorm Child Psychol. 02. 1994;22(1):79-97. X-4, X-10. [pmid: 8163776].
3443 Trudgeon C, Carr D. The Impacts of Home-Based Early Behavioural Intervention Programmes on Families of Children with Autism. Journal of Applied Research in Intellectual Disabilities. 07. 2007;20(4):285-296. X-1, X-4.
3444 Truter I, Kotze TJ. An investigation into the prescribing patterns of selective serotonin re-uptake inhibitors in South Africa. J Clin Pharm Ther. 08. 1996;21(4):237-42. X-4, X-10. [pmid: 8933297].
3445 Tsai LY. Asperger Syndrome and Medication Treatment. Focus on Autism and Other Developmental Disabilities. Fall. 2007;22(3):138-148. X-1, X-2, X-3.
3446 Tsai SJ. TrkB partial agonists: potential treatment strategy for epilepsy, mania, and autism. Med Hypotheses. 2006;66(1):173-5. X-1, X-2, X-3, X-4. [pmid: 16023301].
3447 Tsai WC, Tsai JL, Lotus Shyu YI. Integrating the nurturer-trainer roles: Parental and behavior/symptom management processes for mothers of children with autism. Soc Sci Med. 12. 2008;67(11):1798-806. X-1, X-4. [pmid: 18783863].
3448 Tsakanikos E, Costello H, Holt G, et al. Psychopathology in Adults with Autism and Intellectual Disability. Journal of Autism and Developmental Disorders. 11. 2006;36(8):1123-1129. X-1, X-3, X-4. [pmid: 16855878].
3449 Tsakanikos E, Costello H, Holt G, et al. Behaviour management problems as predictors of psychotropic medication and use of psychiatric services in adults with autism. J Autism Dev Disord. 07. 2007;37(6):1080-5. X-1, X-4. [pmid: 17053989].
3450 Tsakanikos E, Sturmey P, Costello H, et al. Referral trends in mental health services for adults with intellectual disability and autism spectrum disorders. Autism. 01. 2007;11(1):9-17. X-1, X-2, X-3, X-4. [pmid: 17175570].
3451 Tsao L-L, Odom SL. Sibling-Mediated Social Interaction Intervention for Young Children with Autism. Topics in Early Childhood Special Education. Sum. 2006;26(2):106-123. X-3.
3452 Tsatsanis KD. Outcome research in Asperger syndrome and autism. Child Adolesc Psychiatr Clin N Am. 01. 2003;12(1):47-63. vi. X-1, X-2, X-3. [pmid: 12512398].
3453 Tsatsanis KD. Heterogeneity in Learning Style in Asperger Syndrome and High-Functioning Autism. Topics in Language Disorders. 10–12. 2004;24(4):260. X-1, X-2, X-3, X-4.
3454 Tsatsanis KD, Foley C, Donehower C. Contemporary Outcome Research and Programming Guidelines for Asperger Syndrome and High-Functioning Autism. Topics in Language Disorders. 10–12. 2004;24(4):249. X-1, X-2, X-3, X-4.
3455 Tse J, Strulovitch J, Tagalakis V, et al. Social skills training for adolescents with Asperger syndrome and high-functioning autism. J Autism Dev Disord. 11. 2007;37(10):1960-8. X-1, X-3, X-4. [pmid: 17216559].
3456 Tsiantis J, Macri I, Maratos O. Schizophrenia in children: a review of European research. Schizophr Bull. 1986;12(1):101-19. X-1, X-2, X-3, X-4, X-10. [pmid: 3961423].
3457 Tuchman R. Treatment of seizure disorders and EEG abnormalities in children with autism spectrum disorders. J Autism Dev Disord. 10. 2000;30(5):485-9. X-1, X-2, X-3, X-4. [pmid: 11098889].
3458 Tuite DR, Luiten JW. 16PF research into addiction: meta-analysis and extension. Int J Addict. 03. 1986;21(3):287-323. X-1, X-2, X-3, X-4, X-10. [pmid: 3721637].
3459 Turgay A, Binder C, Snyder R, et al. Long-term safety and efficacy of risperidone for the treatment of disruptive behavior disorders in children with subaverage IQs. Pediatrics. 09. 2002;110(3):e34. X-1, X-3, X-4. [pmid: 12205284].
3460 Turnbull A, Edmonson H, Griggs P, et al. A blueprint for schoolwide positive behavior support: Implementation of three components. Exceptional Children. Spr. 2002;68(3):377-402. X-1, X-3, X-4.
3461 Turnbull HR 3rd, Wilcox BL, Stowe MJ. A brief overview of special education law with focus on autism. J Autism Dev Disord. 10. 2002;32(5):479-93. X-1, X-2, X-3, X-4. [pmid: 12463521].
3462 Turner LM, Stone WL. Variability in outcome for children with an ASD diagnosis at age 2. J Child Psychol Psychiatry. 08. 2007;48(8):793-802. X-4. [pmid: 17683451].
3463 Turner LM, Stone WL, Pozdol SL, et al. Follow-up of children with autism spectrum disorders from age 2 to age 9. Autism. 05. 2006;10(3):243-265. X-4. [pmid: 16682397].
3464 Turner-Brown LM, Perry TD, Dichter GS, et al. Brief Report: Feasibility of Social Cognition and Interaction Training for Adults with High Functioning Autism. Journal of Autism and Developmental Disorders. 10. 2008;38(9):1777-1784. X-1. [pmid: 18246419].
3465 Tustin F. Thoughts on autism with special reference to a paper by Melanie Klein. Journal of Child Psychotherapy. 1983;9(2):119-131. X-1, X-2, X-3, X-4, X-10.
3466 Tustin RD. The effects of advance notice of activity transitions on stereotypic behavior. Journal of Applied Behavior Analysis. Spr. 1995;28(1):91-92. X-1, X-4, X-10. [pmid: 16795856].
3467 Tuttle LC. Experiential family therapy: An innovative approach to the resolution of family conflict in genetic counseling. Journal of Genetic Counseling. 04. 1998;7(2):167-186. X-3, X-4, X-10.
3468 Twachtman-Reilly J, Amaral SC, Zebrowski PP. Addressing Feeding Disorders in Children on the Autism Spectrum in School-Based Settings: Physiological and Behavioral Issues. Language, Speech, and Hearing Services in Schools. 04. 2008;39(2):261-272. X-1, X-2, X-3, X-4.
3469 Twoy R, Connolly PM, Novak JM. Coping strategies used by parents of children with autism. J Am Acad Nurse Pract. 05. 2007;19(5):251-60. X-1, X-3, X-4. [pmid: 17489958].
3470 Twyman KA, Maxim RA, Leet TL, et al. Parents’ Developmental Concerns and Age Variance at Diagnosis of Children with Autism Spectrum Disorder. Research in Autism Spectrum Disorders. 04–06. 2009;3(2):489-495. X-4.
3471 Tyminski R. Long-term group psychotherapy for children with pervasive developmental disorders: evidence for group development. Int J Group Psychother. 04. 2005;55(2):189-210. X-2, X-3, X-4. [pmid: 15899759].
3472 Tyrer F, McGrother CW, Thorp CF, et al. Physical Aggression towards Others in Adults with Learning Disabilities: Prevalence and Associated Factors. Journal of Intellectual Disability Research. 04. 2006;50(4):295-304. X-1, X-3, X-4. [pmid: 16507034].
3473 Tyrrell AL, Horn EM, Freeman RL. The Role of the Family in the Positive Behavior Support Process: Team-Based Problem Solving. Young Exceptional Children. 2006;10(1):12-21. X-1, X-2, X-3, X-4.
3474 Uchiyama T, Kurosawa M, Inaba Y. MMR-vaccine and regression in autism spectrum disorders: negative results presented from Japan. J Autism Dev Disord. 02. 2007;37(2):210-7. X-4. [pmid: 16865547].
3475 Uehara I. An attempt at multiple counseling approaches to a client with autistic disabilities. Japanese Journal of Counseling Science. 10. 1999;32(3):301-310. X-1, X-3, X-10.
3476 Umbarger GT III. State of the Evidence Regarding Complimentary and Alternative Medical Treatments for Autism Spectrum Disorders. Education and Training in Developmental Disabilities. 12. 2007;42(4):437-447. X-1, X-2, X-3.
3477 Unwin GL, Deb S. Use of medication for the management of behavior problems among adults with intellectual disabilities: a clinicians’ consensus survey. Am J Ment Retard. 01. 2008;113(1):19-31. X-1, X-4. [pmid: 18173296].
3478 Urban E. The primary self and related concepts in Jung, Klein, and Isaacs. J Anal Psychol. 10. 1992;37(4):411-32. X-1, X-2, X-3, X-4, X-10. [pmid: 1429214].
3479 Usuda J, Tsutsui H, Honda H, et al. Photodynamic therapy for lung cancers based on novel photodynamic diagnosis using talaporfin sodium (NPe6) and autofluorescence bronchoscopy. Lung Cancer. 12. 2007;58(3):317-23. X-1, X-4. [pmid: 17698240].
3480 Uvebrant P, Bauziene R. Intractable epilepsy in children. The efficacy of lamotrigine treatment, including non-seizure-related benefits. Neuropediatrics. 12. 1994;25(6):284-9. X-10. [pmid: 7770124].
3481 Vacca JJ. Incorporating Interests and Structure to Improve Participation of a Child with Autism in a Standardized Assessment: A Case Study Analysis. Focus on Autism and Other Developmental Disabilities. Spr. 2007;22(1):51-59. X-2, X-3, X-4.
3482 Valicenti-McDermott MR, Demb H. Clinical effects and adverse reactions of off-label use of aripiprazole in children and adolescents with developmental disabilities. J Child Adolesc Psychopharmacol. 10. 2006;16(5):549-60. X-1, X-3. [pmid: 17069544].
3483 van Battum LJ, Essers M, Storchi PR. Conversion of measured percentage depth dose to tissue maximum ratio values in stereotactic radiotherapy. Phys Med Biol. 09. 21. 2002;47(18):3289-300. X-1, X-3, X-4. [pmid: 12375821].
3484 Van Berckelaer-Onnes IA. Promoting early play. Autism. 12. 2003;7(4):415-23. X-1, X-3. [pmid: 14678680].
3485 van Berckelaer-Onnes IA, van Loon J, Peelen A. Challenging behaviour: A challenge to change. Autism. 09. 2002;6(3):259-270. X-1, X-3. [pmid: 12212917].
3486 Van Bourgondien ME, Reichle NC, Campbell DG, et al. The Environmental Rating Scale (ERS): a measure of the quality of the residential environment for adults with autism. Res Dev Disabil. 09–10. 1998;19(5):381-94. X-4, X-10. [pmid: 9770251].
3487 Van Bourgondien ME, Reichle NC, Schopler E. Effects of a model treatment approach on adults with autism. J Autism Dev Disord. 04. 2003;33(2):131-40. X-1. [pmid: 12757352].
3488 Van Brunt DL, Johnston JA, Ye W, et al. Predictors of selecting atomoxetine therapy for children with attention-deficit-hyperactivity disorder. Pharmacotherapy. 11. 2005;25(11):1541-9. X-4. [pmid: 16232017].
3489 Van Camp CM, Vollmer TR, Daniel D. A systematic evaluation of stimulus preference, response effort, and stimulus control in the treatment of automatically reinforced self-injury. Behavior Therapy. Sum. 2001;32(3):603-613. X-1, X-3.
3490 van den Hazel P, Zuurbier M, Babisch W, et al. Today’s epidemics in children: possible relations to environmental pollution and suggested preventive measures. Acta Paediatr Suppl. 10. 2006;95(453):18-25. X-2, X-4. [pmid: 17000565].
3491 van den Hazel T, Didden R, Korzilius H. Effects of personality disorder and other variables on professionals’ evaluation of treatment features in individuals with mild intellectual disabilities and severe behavior problems. Res Dev Disabil. 05–06. 2009;30(3):547-57. X-4. [pmid: 18829254].
3492 Van Der Putt R, Dineen C, Janes D, et al. Effectiveness of acetylcholinesterase inhibitors: diagnosis and severity as predictors of response in routine practice. Int J Geriatr Psychiatry. 08. 2006;21(8):755-60. X-1, X-4. [pmid: 16906631].
3493 van der Walt JH, Moran C. An audit of perioperative management of autistic children. Paediatr Anaesth. 07. 2001;11(4):401-8. X-4. [pmid: 11442855].
3494 Van Dyke EM. Autistic disorder: early interventions can improve outcomes. JAAPA. 07. 2009;22(7):18-9. X-1, X-2, X-3, X-4.
3495 van Engeland H. The electrodermal orienting response to auditive stimuli in autistic children, normal children, mentally retarded children, and child psychiatric patients. J Autism Dev Disord. 09. 1984;14(3):261-79. X-4, X-10. [pmid: 6237097].
3496 van Engeland H, Roelofs JW, Verbaten MN, et al. Abnormal electrodermal reactivity to novel visual stimuli in autistic children. Psychiatry Res. 07. 1991;38(1):27-38. X-4, X-10. [pmid: 1946832].
3497 Van Houten R, Rolider A. Recreating the scene: an effective way to provide delayed punishment for inappropriate motor behavior. J Appl Behav Anal. Summer. 1988;21(2):187-92. X-3, X-10. [pmid: 2458333].
3498 van Kraaij DJ, Jansen RW, de Gier JJ, et al. Prescription patterns of diuretics in Dutch community-dwelling elderly patients. Br J Clin Pharmacol. 10. 1998;46(4):403-7. X-1, X-4, X-10. [pmid: 9803990].
3499 Van Soest M. Autism as a result of a dysfunctional hierarchy of the senses: Treatment of autism by Van Soest therapy. Journal of Autism and Developmental Disorders. 12. 1991;21(4):559-561. X-1, X-2, X-3, X-4, X-10. [pmid: 1778969].
3500 VanBergeijk E, Klin A, Volkmar F. Supporting More Able Students on the Autism Spectrum: College and Beyond. Journal of Autism and Developmental Disorders. 08. 2008;38(7):1359-1370. X-1, X-2, X-3. [pmid: 18172747].
3501 VanMeter L, Fein D, Morris R, et al. Delay versus deviance in autistic social behavior. J Autism Dev Disord. 10. 1997;27(5):557-69. X-4, X-10. [pmid: 9403372].
3502 Varley C, Kolff C, Trupin E, et al. Hemodialysis as a treatment for infantile autism. J Autism Dev Disord. 12. 1980;10(4):399-404. X-3, X-10. [pmid: 6927743].
3503 Varley CK, Holm VA. A two-year follow-up of autistic children treated with fenfluramine. Journal of the American Academy of Child & Adolescent Psychiatry. 01. 1990;29(1):137-140. X-3, X-10. [pmid: 2295567].
3504 Vaughn BJ, Wilson D, Dunlap G. Family-centered intervention to resolve problem behaviors in a fast-food restaurant. Journal of Positive Behavior Interventions. Win. 2002;4(1):38-45. X-3.
3505 Vazquez CA. Brief report: a multitask controlled evaluation of facilitated communication. J Autism Dev Disord. 06. 1994;24(3):369-79. X-10. [pmid: 8050989].
3506 Vázquez CA. Failure to confirm the word-retrieval problem hypothesis in facilitated communication. Journal of Autism and Developmental Disorders. 12. 1995;25(6):597-610. X-10. [pmid: 8720029].
3507 Venn ML, Wolery M, Greco M. Effects of every-day and every-other-day instruction. Focus on Autism and Other Developmental Disabilities. Spr. 1996;11(1):15-28. X-3, X-10.
3508 Venn ML, Wolery M, Werts MG, et al. Embedding instruction in art activities to teach preschoolers with disabilities to imitate their peers. Early Childhood Research Quarterly. 09. 1993;8(3):277-294. X-10.
3509 Venselaar JL, Bierhuizen HW. A solution for the treatment of small lesions using electron beams from a Saturne linear accelerator with continuous variable trimmers; dosimetrical aspects. Med Dosim. Summer. 1998;23(2):99-103. X-1, X-2, X-3, X-4, X-10. [pmid: 9664275].
3510 Venselaar JL, Heukelom S, Jager HN, et al. Is there a need for a revised table of equivalent square fields for the determination of phantom scatter correction factors?. Phys Med Biol. 12. 1997;42(12):2369-81. X-1, X-3, X-4, X-10. [pmid: 9434294].
3511 Verbaten MN, Kemner C, Buitelaar JK, et al. Effects of ORG-2766 on brain event-related potentials of autistic children. Psychiatry Res. 06. 26. 1996;63(1):33-45. X-10. [pmid: 8832772].
3512 Vered Y, Golubchik P, Mozes T, et al. The platelet-poor plasma 5-HT response to carbohydrate rich meal administration in adult autistic patients compared with normal controls. Human Psychopharmacology: Clinical and Experimental. 07. 2003;18(5):395-399. X-1, X-4. [pmid: 12858328].
3513 Verheij F, Van Doorn EC. Autism and mental retardation: the planning of a therapeutic environment. Int J Rehabil Res. 1990;13(2):127-36. X-1, X-2, X-3, X-4, X-10. [pmid: 2269556].
3514 Vessey JA. Care of the hospitalized child with a cognitive developmental delay. Holist Nurs Pract. 02. 1988;2(2):48-54. X-10. [pmid: 2447107].
3515 Vig S, Jedrysek E. Adaptive behavior of young urban children with developmental disabilities. Ment Retard. 04. 1995;33(2):90-8. X-4, X-10. [pmid: 7760730].
3516 Viola S, Noddings A. Making Sense of Every Child. Montessori Life: A Publication of the American Montessori Society. 2006;18(4):40-47. X-3.
3517 Vismara LA, Colombi C, Rogers SJ. Can one hour per week of therapy lead to lasting changes in young children with autism?. Autism. 01. 2009;13(1):93-115. X-3. [pmid: 19176579].
3518 Vismara LA, Lyons GL. Using Perseverative Interests to Elicit Joint Attention Behaviors in Young Children with Autism: Theoretical and Clinical Implications for Understanding Motivation. Journal of Positive Behavior Interventions. 2007;9(4):214-228. X-3.
3519 Vismara LA, Rogers SJ. The Early Start Denver Model: A Case Study of an Innovative Practice. Journal of Early Intervention. 2008;31(1):91-108. X-3.
3520 Visser M, Singer E, van Geert PLC, et al. What Makes Children Behave Aggressively? The Inner Logic of Dutch Children in Special Education. European Journal of Special Needs Education. 02. 2009;24(1):1-20. X-1, X-4.
3521 Vitiello B. An update on publicly funded multisite trials in pediatric psychopharmacology. Child Adolesc Psychiatr Clin N Am. 01. 2006;15(1):1-12. X-2, X-3. [pmid: 16321723].
3522 Vitiello B. Recent NIMH clinical trials and implications for practice. J Am Acad Child Adolesc Psychiatry. 12. 2008;47(12):1369-74. X-2, X-3. [pmid: 19034188].
3523 Vitiello B, Aman MG, Scahill L, et al. Research knowledge among parents of children participating in a randomized clinical trial. J Am Acad Child Adolesc Psychiatry. 02. 2005;44(2):145-9. X-1, X-4. [pmid: 15689727].
3524 Vitiello B, Davies M, Arnold LE, et al. Assessment of the integrity of study blindness in a pediatric clinical trial of risperidone. J Clin Psychopharmacol. 12. 2005;25(6):565-9. X-1, X-4. [pmid: 16282839].
3525 Vlamings PH, Jonkman LM, Hoeksma MR, et al. Reduced error monitoring in children with autism spectrum disorder: an ERP study. Eur J Neurosci. 07. 2008;28(2):399-406. X-4. [pmid: 18702711].
3526 Volden J, Coolican J, Garon N, et al. Brief Report: Pragmatic Language in Autism Spectrum Disorder--Relationships to Measures of Ability and Disability. Journal of Autism and Developmental Disorders. 02. 2009;39(2):388-393. X-4. [pmid: 18626760].
3527 Volden J, Lord C. Neologisms and idiosyncratic language in autistic speakers. J Autism Dev Disord. 06. 1991;21(2):109-30. X-4, X-10. [pmid: 1864825].
3528 Volden J, Magill-Evans J, Goulden K, et al. Varying Language Register According to Listener Needs in Speakers with Autism Spectrum Disorder. Journal of Autism and Developmental Disorders. 07. 2007;37(6):1139-1154. X-4. [pmid: 17160460].
3529 Volden J, Sorenson A. Bossy and nice requests: varying language register in speakers with autism spectrum disorder (ASD). J Commun Disord. 01–02. 2009;42(1):58-73. X-4. [pmid: 18930471].
3530 Volker MA, Lopata C. Autism: A Review of Biological Bases, Assessment, and Intervention. School Psychology Quarterly. 06. 2008;23(2):258-270. X-1, X-2, X-3, X-4.
3531 Volkert VM, Lerman DC, Call NA, et al. An Evaluation of Resurgence during Treatment with Functional Communication Training. Journal of Applied Behavior Analysis. Spr. 2009;42(1):145-160. X-3. [pmid: 19721735].
3532 Volkert VM, Lerman DC, Trosclair N, et al. An exploratory analysis of task-interspersal procedures while teaching object labels to children with autism. J Appl Behav Anal. Fall. 2008;41(3):335-50. X-3. [pmid: 18816973].
3533 Volkert VM, Lerman DC, Vorndran C. The effects of reinforcement magnitude on functional analysis outcomes. J Appl Behav Anal. Summer. 2005;38(2):147-62. X-3, X-4. [pmid: 16033163].
3534 Volkmar F. Recently diagnosed with autism, autism or not. J Autism Dev Disord. 06. 1998;28(3):269-70. X-10. [pmid: 9656140].
3535 Volkmar F. What is a “placebo controlled” study?. J Autism Dev Disord. 04. 2001;31(2):251-2. X-1, X-2, X-3, X-4. [pmid: 11450827].
3536 Volkmar F. Predicting outcome in autism. J Autism Dev Disord. 02. 2002;32(1):63-4. X-1, X-2, X-3, X-4. [pmid: 11916336].
3537 Volkmar F. Ask the editor. J Autism Dev Disord. 04. 2006;36(3):437-8. X-2. [pmid: 16586156].
3538 Volkmar FR, Cohen DJ. Current concepts: infantile autism and the pervasive developmental disorders. J Dev Behav Pediatr. 10. 1986;7(5):324-9. X-1, X-2, X-3, X-4, X-10. [pmid: 3771807].
3539 Volkmar FR, Hoder EL, Cohen DJ. Compliance, ‘negativism’, and the effects of treatment structure in autism: a naturalistic, behavioral study. J Child Psychol Psychiatry. 11. 1985;26(6):865-77. X-10. [pmid: 4066813].
3540 Volkmar FR, Hoder EL, Cohen DJ. Inappropriate uses of stimulant medications. Clinical Pediatrics. 03. 1985;24(3):127-130. X-1, X-3, X-4, X-10. [pmid: 2578911].
3541 Volkmar FR, Klin A, Schultz RT, et al. Asperger’s disorder. American Journal of Psychiatry. 02. 2000;157(2):262-267. X-3, X-4. [pmid: 10671397].
3542 Volkmar FR, Rutter M. Childhood disintegrative disorder: results of the DSM-IV autism field trial. J Am Acad Child Adolesc Psychiatry. 08. 1995;34(8):1092-5. X-1, X-4, X-10. [pmid: 7665448].
3543 Volkmar FR, Sparrow SS, Goudreau D, et al. Social deficits in autism: an operational approach using the Vineland Adaptive Behavior Scales. J Am Acad Child Adolesc Psychiatry. 03. 1987;26(2):156-61. X-10. [pmid: 3584011].
3544 Vollmer TR, Borrero JC, Lalli JS, et al. Evaluating self-control and impulsivity in children with severe behavior disorders. J Appl Behav Anal. Winter. 1999;32(4):451-66. X-3, X-10. [pmid: 10641300].
3545 Vonder Hulls DS, Walker LK, Powell JM. Clinicians’ perceptions of the benefits of aquatic therapy for young children with autism: a preliminary study. Phys Occup Ther Pediatr. 2006;26(1–2):13-22. X-1. [pmid: 16938823].
3546 Wachtel K, Carter AS. Reaction to Diagnosis and Parenting Styles among Mothers of Young Children with ASDs. Autism: The International Journal of Research and Practice. 2008;12(5):575-594. X-4. [pmid: 18805948].
3547 Wachtel LE, Contrucci-Kuhn SA, Griffin M, et al. ECT for self-injury in an autistic boy. European Child & Adolescent Psychiatry. 2009;18(7):3. X-3.
3548 Wager KM. The effects of music therapy upon an adult male with autism and mental retardation: A four-year case study. Music Therapy Perspectives. 2000;18(2):131-140. X-1, X-3.
3549 Wagner A, Lecavalier L, Arnold LE, et al. Developmental disabilities modification of the Children’s Global Assessment Scale. Biol Psychiatry. 02. 15. 2007;61(4):504-11. X-4. [pmid: 17276748].
3550 Wagner EE, Wagner CF, Hilsenroth MJ, et al. A taxonomy of Rorschach autisms with implications for differential diagnosis among thinking-disordered patients. J Clin Psychol. 03. 1995;51(2):290-3. X-1, X-4, X-10. [pmid: 7797654].
3551 Waite LM, Broe GA, Grayson DA, et al. Motor function and disability in the dementias. Int J Geriatr Psychiatry. 10. 2000;15(10):897-903. X-1, X-4. [pmid: 11044871].
3552 Wakschlag LS, Leventhal BL. Consultation with young autistic children and their families. J Am Acad Child Adolesc Psychiatry. 07. 1996;35(7):963-5. X-10. [pmid: 8768359].
3553 Walenski M, Mostofsky SH, Gidley-Larson JC, et al. Brief Report: Enhanced Picture Naming in Autism. Journal of Autism and Developmental Disorders. 08. 2008;38(7):1395-1399. X-4. [pmid: 18163206].
3554 Walker G. Constant and progressive time delay procedures for teaching children with autism: a literature review. J Autism Dev Disord. 02. 2008;38(2):261-75. X-2. [pmid: 17546491].
3555 Walkup JT, Albano AM, Piacentini J, et al. Cognitive behavioral therapy, sertraline, or a combination in childhood anxiety. N Engl J Med. 12. 25. 2008;359(26):2753-66. X-1, X-3, X-4. [pmid: 18974308].
3556 Wall ME, Gast DL. Caregivers’ use of constant time delay to teach leisure skills to adolescents or young adults with moderate or severe intellectual disabilities. Education & Training in Mental Retardation & Developmental Disabilities. 12. 1997;32(4):340-356. X-1, X-3, X-10.
3557 Wallace C, Leask J, Trevena LJ. Effects of a web based decision aid on parental attitudes to MMR vaccination: a before and after study. BMJ. 01. 21. 2006;332(7534):146-9. X-1, X-4. [pmid: 16352657].
3558 Walley T, Folino-Gallo P, Stephens P, et al. Trends in prescribing and utilization of statins and other lipid lowering drugs across Europe 1997–2003. Br J Clin Pharmacol. 11. 2005;60(5):543-51. X-1, X-4. [pmid: 16236045].
3559 Walters AS, Barrett RP, Feinstein C, et al. A case report of naltrexone treatment of self-injury and social withdrawal in autism. Journal of Autism and Developmental Disorders. 06. 1990;20(2):169-176. X-1, X-3, X-10. [pmid: 2189867].
3560 Walworth DD. The use of music therapy within the SCERTS model for children with Autism Spectrum Disorder. J Music Ther. Spring. 2007;44(1):2-22. X-1, X-4. [pmid: 17419661].
3561 Walworth DD, Register D, Engel JN. Using the SCERTS model assessment tool to identify music therapy goals for clients with autism spectrum disorder. J Music Ther. Fall. 2009;46(3):204-16. X-4. [pmid: 19757876].
3562 Wang PP. International adoption: A four-year-old child with unusual behaviors adopted at six months of age: Paul P. Wang, M.D. Journal of Developmental & Behavioral Pediatrics. 02. 2003;24(1):68-69. X-3, X-4.
3563 Wang S-Y, Parrila R. Quality Indicators for Single-Case Research on Social Skill Interventions for Children with Autistic Spectrum Disorder. Developmental Disabilities Bulletin. 2008;36(1–2):81-105. X-1, X-2, X-3, X-4.
3564 Wank R. Schizophrenia and other mental disorders require long-term adoptive immunotherapy. Med Hypotheses. 08. 2002;59(2):154-8. X-3. [pmid: 12208201].
3565 Ward P, Ayvazo S. Classwide Peer Tutoring in Physical Education: Assessing Its Effects With Kindergartners With Autism. Adapted Physical Activity Quarterly. 07. 2006;23(3):233-244. X-3.
3566 Warwick TC, Griffith J, Reyes B, et al. Effects of vagus nerve stimulation in a patient with temporal lobe epilepsy and Asperger syndrome: case report and review of the literature. Epilepsy Behav. 03. 2007;10(2):344-7. X-1, X-3. [pmid: 17300990].
3567 Wasdell MB, Jan JE, Bomben MM, et al. A randomized, placebo-controlled trial of controlled release melatonin treatment of delayed sleep phase syndrome and impaired sleep maintenance in children with neurodevelopmental disabilities. J Pineal Res. 01. 2008;44(1):57-64. X-3. [pmid: 18078449].
3568 Wasserman S, Iyengar R, Chaplin WF, et al. Levetiracetam versus placebo in childhood and adolescent autism: a double-blind placebo-controlled study. Int Clin Psychopharmacol. 11. 2006;21(6):363-7. X-3. [pmid: 17012983].
3569 Watanabe M, Sturmey P. The effect of choice-making opportunities during activity schedules on task engagement of adults with autism. J Autism Dev Disord. 10. 2003;33(5):535-8. X-1, X-3. [pmid: 14594333].
3570 Watling R, Deitz J, Kanny EM, et al. Current practice of occupational therapy for children with autism. Am J Occup Ther. 09–10. 1999;53(5):498-505. X-1, X-4, X-10. [pmid: 10500858].
3571 Watling R, Tomchek S, LaVesser P. The scope of occupational therapy services for individuals with autism spectrum disorders across the lifespan. Am J Occup Ther. 11–12. 2005;59(6):680-3. X-1, X-2, X-3, X-4. [pmid: 16363193].
3572 Watling RL, Deitz J, White O. Comparison of Sensory Profile scores of young children with and without autism spectrum disorders. Am J Occup Ther. 07–08. 2001;55(4):416-23. X-1, X-4. [pmid: 11723986].
3573 Watling RL, Dietz J. Immediate effect of Ayres’s sensory integration-based occupational therapy intervention on children with autism spectrum disorders. Am J Occup Ther. 09–10. 2007;61(5):574-83. X-3. [pmid: 17944295].
3574 Watson LR. Following the child’s lead: mothers’ interactions with children with autism. J Autism Dev Disord. 02. 1998;28(1):51-9. X-4, X-10. [pmid: 9546302].
3575 Watson SL. “Something You Have to Do”--Why Do Parents of Children with Developmental Disabilities Seek a Differential Diagnosis?. Developmental Disabilities Bulletin. 2008;36(1–2):168-198. X-1, X-4.
3576 Watters RG, Watters WE. Decreasing self-stimulatory behavior with physical exercise in a group of autistic boys. J Autism Dev Disord. 12. 1980;10(4):379-87. X-3, X-10. [pmid: 6927742].
3577 Watters RG, Wheeler LJ, Watters WE. The relative efficiency of two orders for training autistic children in the expressive and receptive use of manual signs. J Commun Disord. 07. 1981;14(4):273-85. X-3, X-10. [pmid: 7263933].
3578 Webb BJ, Miller SP, Pierce TB, et al. Effects of Social Skill Instruction for High-Functioning Adolescents with Autism Spectrum Disorders. Focus on Autism and Other Developmental Disabilities. Spr. 2004;19(1):53-62. X-1, X-3.
3579 Webb T. Can Children with Autism and Severe Learning Disabilities Be Taught to Communicate Spontaneously and Effectively Using the Picture Exchange Communication System?. Good Autism Practice. 2000;1:29-41. X-2, X-3.
3580 Weber BP, Dillo W, Dietrich B, et al. Pediatric cochlear implantation in cochlear malformations. Am J Otol. 11. 1998;19(6):747-53. X-1, X-4, X-10. [pmid: 9831148].
3581 Weber RC, Thorpe J. Teaching children with autism through task variation in physical education. Except Child. 09. 1992;59(1):77-86. X-10. [pmid: 1396953].
3582 Webster A, Feiler A, Webster V, et al. Parental Perspectives on Early Intensive Intervention for Children Diagnosed with Autistic Spectrum Disorder. Journal of Early Childhood Research. 2004;2(1):25-49. X-1, X-3, X-4.
3583 Wegner LM, Macias MM. Services for children and adolescents with autism spectrum disorders: payment issues. Pediatr Ann. 01. 2009;38(1):57-61. X-2, X-3, X-4. [pmid: 19213294].
3584 Wehman P, Kregel J. Supported competitive employment for individuals with autism and severe retardation: Two case studies. Focus on Autistic Behavior. 08. 1988;3(3):14. X-1, X-3, X-4, X-10.
3585 Weintraub FJ, Myers RM, Hehir T, et al. A Contextual Overview of the Modified Consent Decree in the Los Angeles Unified School District. Journal of Special Education Leadership. 09. 2008;21(2):51-57. X-1, X-2, X-3, X-4.
3586 Weiskop S, Matthews J, Richdale A. Treatment of sleep problems in a 5-year-old boy with autism using behavioural principles. Autism. 06. 2001;5(2):209-221. X-3. [pmid: 11706867].
3587 Weiskop S, Richdale A, Matthews J. B ehavioural treatment to reduce sleep problems in children with autism or fragile X syndrome. Dev Med Child Neurol. 02. 2005;47(2):94-104. X-3. [pmid: 15707232].
3588 Weiss MJ. Differential rates of skill acquisition and outcomes of early intensive behavioral intervention for autism. Behavioral Interventions. 01–03. 1999;14(1):3-22. X-10.
3589 Weiss MJ. Comprehensive ABA programs: Integrating and evaluating the implementation of varied instructional approaches. The Behavior Analyst Today. 2005;6(4):249-256. X-1, X-2, X-3.
3590 Weiss MJS, Wagner SH, Bauman ML. A validated case study of facilitated communication. Mental Retardation. 08. 1996;34(4):220-230. X-10. [pmid: 8828341].
3591 Weiss SJ. Personality adjustment and social support of parents who care for children with pervasive developmental disorders. Arch Psychiatr Nurs. 02. 1991;5(1):25-30. X-1, X-4, X-10. [pmid: 2039277].
3592 Weiss SJ. Stressors experienced by family caregivers of children with pervasive developmental disorders. Child Psychiatry Hum Dev. Spring. 1991;21(3):203-16. X-1, X-4, X-10. [pmid: 2007345].
3593 Weizman R, Gil-Ad I, Dick J, et al. Low plasma immunoreactive !b-endorphin levels in autism. Journal of the American Academy of Child & Adolescent Psychiatry. 07. 1988;27(4):430-433. X-10. [pmid: 2972691].
3594 Wek SR, Husak WS. Distributed and massed practice effects on motor performance and learning of autistic children. Percept Mot Skills. 02. 1989;68(1):107-13. X-3, X-10. [pmid: 2928030].
3595 Welch MG. Toward prevention of developmental disorders. Pa Med. 03. 1987;90(3):47-52. X-10.
3596 Welch MG, Chaput P. Mother-child holding therapy and autism. Pa Med. 10. 1988;91(10):33-8. X-10.
3597 Wellman HM, Baron-Cohen S, Caswell R, et al. Thought-bubbles help children with autism acquire an alternative to a theory of mind. Autism. 12. 2002;6(4):343-363. X-1, X-3. [pmid: 12540127].
3598 Welterlin A, LaRue RH. Serving the Needs of Immigrant Families of Children with Autism. Disability & Society. 12. 2007;22(7):747-760. X-1, X-2, X-3, X-4.
3599 Werber EA, Rabey JM. The beneficial effect of cholinesterase inhibitors on patients suffering from Parkinson’s disease and dementia. J Neural Transm. 2001;108(11):1319-25. X-1, X-4. [pmid: 11768630].
3600 Wernicke JF, Kratochvil CJ. Safety profile of atomoxetine in the treatment of children and adolescents with ADHD. J Clin Psychiatry. 2002;63(Suppl 12):50-5. X-1, X-2, X-3, X-4. [pmid: 12562062].
3601 Wert BY, Neisworth JT. Effects of video self-modeling on spontaneous requesting in children with autism. Journal of Positive Behavior Interventions. Win. 2003;5(1):30-34. X-3.
3602 West EA, Billingsley F. Improving the System of Least Prompts: A Comparison of Procedural Variations, Education and Training in Developmental Disabilities Journal Citation. 06. 2005;40(2):131-144. Publisher: Division on Developmental Disabilities, Council for Exceptional Children. DDD, PO Box 3512, Fayetteville, AR 72702. Tel: 479-575-3326; Fax: 479-575-6676; Web site: http://www.dddcec.org. 2005 06-00 Pub Types: Journal Articles; Reports - Evaluative. X-3.
3603 West L, Waldrop J, Brunssen S. Pharmacologic treatment for the core deficits and associated symptoms of autism in children. J Pediatr Health Care. 03–04. 2009;23(2):75-89. X-2. [pmid: 19232924].
3604 Wetherby AM. Ontogeny of communicative functions in autism. J Autism Dev Disord. 09. 1986;16(3):295-316. X-1, X-2, X-3, X-4, X-10. [pmid: 3558289].
3605 Wetherby AM, Prutting CA. Profiles of communicative and cognitive-social abilities in autistic children. Journal of Speech & Hearing Research. 09. 1984;27(3):364-377. X-3, X-4, X-10. [pmid: 6482406].
3606 Whalen C, Schreibman L. Joint attention training for children with autism using behavior modification procedures. J Child Psychol Psychiatry. 03. 2003;44(3):456-68. X-3, X-4. [pmid: 12635974].
3607 Whalen C, Schreibman L, Ingersoll B. The collateral effects of joint attention training on social initiations, positive affect, imitation, and spontaneous speech for young children with autism. J Autism Dev Disord. 07. 2006;36(5):655-64. X-3. [pmid: 16810564].
3608 Whalon K, Hanline MF. Effects of a Reciprocal Questioning Intervention on the Question Generation and Responding of Children with Autism Spectrum Disorder. Education and Training in Developmental Disabilities. 09. 2008;43(3):367-387. X-3.
3609 Wheeler DL, Jacobson JW, Paglieri RA, et al. An experimental assessment of facilitated communication. Ment Retard. 02. 1993;31(1):49-59. X-1, X-10. [pmid: 8441353].
3610 Wheeler JJ, Baggett BA, Fox J, et al. Treatment Integrity: A Review of Intervention Studies Conducted with Children with Autism. Focus on Autism and Other Developmental Disabilities. Spr. 2006;21(1):45-54. X-1, X-2, X-3, X-4.
3611 Wheeler JJ, Carter SL, Mayton MR, et al. Preventing Challenging Behaviour through the Management of Instructional Antecedents. Developmental Disabilities Bulletin. 2006;34(1–2):1-14. X-1, X-2, X-3, X-4.
3612 Whipple J. Music in intervention for children and adolescents with Autism: A meta-analysis. Journal of Music Therapy. Sum. 2004;41(2):90-106. X-1, X-3, X-4. [pmid: 15307805].
3613 White SW, Ollendick T, Scahill L, et al. Preliminary Efficacy of a Cognitive-Behavioral Treatment Program for Anxious Youth with Autism Spectrum Disorders. Journal of Autism and Developmental Disorders. 12. 2009;39(12):1652-1662. X-1, X-3.
3614 White SW, Scahill L, Klin A, et al. Educational placements and service use patterns of individuals with autism spectrum disorders. J Autism Dev Disord. 09. 2007;37(8):1403-12. X-4. [pmid: 17082975].
3615 Whitehouse AJ, Bishop DV. Do children with autism ‘switch off’ to speech sounds? An investigation using event-related potentials. Dev Sci. 07. 2008;11(4):516-24. X-4. [pmid: 18576959].
3616 Whiteley P. Autism unravelled conference--’the biology of autism--unravelled’. Expert Opin Pharmacother. 07. 2001;2(7):1191-3. X-1, X-2, X-3, X-4. [pmid: 11583070].
3617 Whiteley P, Rodgers J, Savery D, et al. A gluten-free diet as an intervention for autism and associated spectrum disorders: Preliminary findings. Autism. 03. 1999;3(1):45-65. X-10.
3618 Whiteley P, Rodgers J, Shattock P. MMR and autism. Autism. 06. 2000;4(2):207-211. X-4.
3619 Whitenstall M. My life with Asperger’s syndrome. Arch Dis Child. 03. 2004;89(3):281. X-2, X-3, X-4. [pmid: 14977714].
3620 Whittingham K, Sofronoff K, Sheffield JK. Stepping Stones Triple P: a pilot study to evaluate acceptability of the program by parents of a child diagnosed with an Autism Spectrum Disorder. Res Dev Disabil. 07–08. 2006;27(4):364-80. X-1, X-4. [pmid: 16051461].
3621 Wick JY, Zanni GR. Autism and aging: hardly out of the woods. Consult Pharm. 09. 2009;24(9):648-50. 653. 60. X-1, X-2, X-3, X-4. [pmid: 19842781].
3622 Wieder S, Greenspan S. Can Children with Autism Master the Core Deficits and Become Empathetic, Creative, and Reflective? A Ten to Fifteen Year Follow-Up of a Subgroup of Children with Autism Spectrum Disorders (ASD) Who Received a Comprehensive Developmental, Individual-Difference, Relationship-Based (DIR) Approach. Journal of Developmental and Learning Disorders. 2005. 2005;9:39-61. X-1, X-3.
3623 Wiggins LD, Bakeman R, Adamson LB, et al. The Utility of the Social Communication Questionnaire in Screening for Autism in Children Referred for Early Intervention. Focus on Autism and Other Developmental Disabilities. Spr. 2007;22(1):33-38. X-4.
3624 Wiggs L, France K. Behavioural treatments for sleep problems in children and adolescents with physical illness, psychological problems or intellectual disabilities. Sleep Med Rev. 06. 2000;4(3):299-314. X-1, X-3. [pmid: 12531171].
3625 Wigram T. Evidence from assessment that can identfy the expectations of music therapy as a treatment for Autistic Spectrum Disorder (ASD): meeting the challenge of Evidence Based Practice. British Journal of Music Therapy. 2002;16(1). X-3, X-4.
3626 Wilczynski SM, Fusilier I, Dubard M, et al. Experimental Analysis of Proximity as a Social Stimulus: Increasing On-Task Behavior of an Adolescent with Autism. Psychology in the Schools. 02. 2005;42(2):189-196. X-1, X-3.
3627 Wilczynski SM, Menousek K, Hunter M, et al. Individualized Education Programs for Youth with Autism Spectrum Disorders. Psychology in the Schools. 09. 2007;44(7):653-666. X-1, X-2, X-3, X-4.
3628 Wiley S, Choo D, Meinzen-Derr J, et al. GJB2 mutations and additional disabilities in a pediatric cochlear implant population. Int J Pediatr Otorhinolaryngol. 03. 2006;70(3):493-500. X-1, X-4. [pmid: 16154643].
3629 Wilkins D, Li XA, Cygler J, et al. The effect of dose rate dependence of p-type silicon detectors on linac relative dosimetry. Med Phys. 06. 1997;24(6):879-81. X-1, X-3, X-4, X-10. [pmid: 9198022].
3630 Wilkinson LA. Supporting the Inclusion of a Student with Asperger Syndrome: A Case Study using Conjoint Behavioural Consultation and Self-management. Educational Psychology in Practice. 12. 2005;21(4):307-326. X-3.
3631 Wilkinson LA. Self-Management for Children with High-Functioning Autism Spectrum Disorders. Intervention in School and Clinic. 2008;43(3):150-157. X-1, X-2, X-3, X-4.
3632 Willemsen-Swinkels SH, Buitelaar JK, Nijhof GJ, et al. Failure of naltrexone hydrochloride to reduce self-injurious and autistic behavior in mentally retarded adults. Double-blind placebo-controlled studies. Arch Gen Psychiatry. 09. 1995;52(9):766-73. X-1, X-10. [pmid: 7654128].
3633 Willemsen-Swinkels SH, Buitelaar JK, van Berckelaer-Onnes IA, et al. Brief report: six months continuation treatment in naltrexone-responsive children with autism: an open-label case-control design. J Autism Dev Disord. 04. 1999;29(2):167-9. X-10. [pmid: 10382138].
3634 Willemsen-Swinkels SH, Buitelaar JK, van Engeland H. The effects of chronic naltrexone treatment in young autistic children: a double-blind placebo-controlled crossover study. Biol Psychiatry. 06. 15. 1996;39(12):1023-31. X-10. [pmid: 8780837].
3635 Willemsen-Swinkels SH, Buitelaar JK, Weijnen FG, et al. Placebo-controlled acute dosage naltrexone study in young autistic children. Psychiatry Res. 10. 16. 1995;58(3):203-15. X-10. [pmid: 8570776].
3636 Willemsen-Swinkels SHN, Buitelaar JK, van Berckelaer-Onnes IA, et al. Six months continuation treatment in naltrexone-responsive children with autism: An open-label case-control design. Journal of Autism and Developmental Disorders. 04. 1999;29(2):167-169. X-3, X-10. [pmid: 10382138].
3637 Williams B. Mental handicap nursing. Autism--help for the family. Nurs Times. 08. 21–27. 1991;87(34):61-3. X-1, X-2, X-3, X-4, X-10.
3638 Williams C, Wright B, Callaghan G, et al. Do children with autism learn to read more readily by computer assisted instruction or traditional book methods? A pilot study. Autism. 03. 2002;6(1):71-91. X-3. [pmid: 11918110].
3639 Williams DE, Kirkpatrick-Sanchez S, Crocker WT. A long-term follow-up of treatment for severe self-injury. Research in Developmental Disabilities. 11–12. 1994;15(6):487-501. X-1, X-3, X-10. [pmid: 7871235].
3640 Williams E, Kendell-Scott L, Costall A. Parents’ experiences of introducing everyday object use to their children with autism. Autism. 12. 2005;9(5):495-514. X-1, X-4. [pmid: 16287702].
3641 Williams E, Reddy V, Costall A. Taking a closer look at functional play in children with autism. J Autism Dev Disord. 02. 2001;31(1):67-77. X-4. [pmid: 11439756].
3642 Williams G, Carnerero JJ, Perez-Gonzalez LA. Generalization of tacting actions in children with autism. J Appl Behav Anal. Summer. 2006;39(2):233-7. X-3. [pmid: 16813044].
3643 Williams G, Donley CR, Keller JW. Teaching children with autism to ask questions about hidden objects. Journal of Applied Behavior Analysis. Special Issue: Establishing operations in applied behavior analysis. Win. 2000;33(4):627-630. X-3.
3644 Williams G, King J, Cunningham M, et al. Fetal valproate syndrome and autism: additional evidence of an association. Dev Med Child Neurol. 03. 2001;43(3):202-6. X-3, X-4. [pmid: 11263692].
3645 Williams G, Perez-Gonzalez LA, Vogt K. The role of specific consequences in the maintenance of three types of questions. J Appl Behav Anal. Fall. 2003;36(3):285-96. X-3. [pmid: 14596570].
3646 Williams J, Brayne C. Screening for Autism Spectrum Disorders: What Is the Evidence?. Autism: The International Journal of Research & Practice. 2006;10(1):11-35. X-1, X-2, X-3, X-4. [pmid: 16522708].
3647 Williams JA, Koegel RL, Egel AL. Response-reinforcer relationships and improved learning in autistic children. J Appl Behav Anal. Spring. 1981;14(1):53-60. X-10. [pmid: 7216932].
3648 Williams JH, Massaro DW, Peel NJ, et al. Visual-auditory integration during speech imitation in autism. Res Dev Disabil. 11–12. 2004;25(6):559-75. X-4. [pmid: 15541632].
3649 Williams K, Leonard H, Tursan d’Espaignet E, et al. Hospitalisations from birth to 5 years in a population cohort of Western Australian children with intellectual disability. Arch Dis Child. 12. 2005;90(12):1243-8. X-4. [pmid: 16301550].
3650 Williams KE, Gibbons BG, Schreck KA. Comparing Selective Eaters with and Without Developmental Disabilities. Journal of Developmental and Physical Disabilities. 09. 2005;17(3):299-309. X-4.
3651 Williams KR. The Son-Rise Program intervention for autism: prerequisites for evaluation. Autism. 01. 2006;10(1):86-102. X-3, X-4. [pmid: 16522712].
3652 Williams KR, Wishart JG. The Son-Rise Program intervention for autism: an investigation into family experiences. J Intellect Disabil Res. 05–06. 2003;47(Pt 4–5):291-9. X-4. [pmid: 12787161].
3653 Williams KW, Wray JJ, Wheeler DM. Intravenous secretin for autism spectrum disorder. Cochrane Database Syst Rev. 2005;(3):CD003495. X-2.
3654 Williams PG, Allard A, Sears L, et al. Brief report: case reports on naltrexone use in children with autism: controlled observations regarding benefits and practical issues of medication management. J Autism Dev Disord. 02. 2001;31(1):103-8. X-3. [pmid: 11439748].
3655 Williams PG, Allard AM, Sears L, et al. Brief report: Case reports on naltexone use in children with autism: Controlled observations regarding benefits and practical issues of medication management. Journal of Autism and Developmental Disorders. 02. 2001;31(1):103-108. X-3. [pmid: 11439748].
3656 Williams PG, Dalrymple N, Neal J. Eating habits of children with autism. Pediatr Nurs. 05–06. 2000;26(3):259-64. X-1, X-2, X-3, X-4. [pmid: 12026389].
3657 Williams PG, Hersh JH, Allard A, et al. A Controlled Study of Mercury Levels in Hair Samples of Children with Autism as Compared to Their Typically Developing Siblings. Research in Autism Spectrum Disorders. 01–03. 2008;2(1):170-175. X-4.
3658 Williams SK, Johnson C, Sukhodolsky DG. The Role of the School Psychologist in the Inclusive Education of School-Age Children with Autism Spectrum Disorders. Journal of School Psychology. 03. 2005;43(2):117-136. X-1, X-2, X-3, X-4.
3659 Williams TI. A social skills group for autistic children. J Autism Dev Disord. 03. 1989;19(1):143-55. X-10. [pmid: 2708297].
3660 Williams TI. Evaluating effects of aromatherapy massage on sleep in children with autism: a pilot study. Evid Based Complement Alternat Med. 09. 2006;3(3):373-7. X-1. [pmid: 16951722].
3661 Williams White S, Keonig K, Scahill L. Social Skills Development in Children with Autism Spectrum Disorders: A Review of the Intervention Research. Journal of Autism and Developmental Disorders. 11. 2007;37(10):1858-1868. X-1, X-2, X-3. [pmid: 17195104].
3662 Williams-Diehm KL, Lynch PS. Student Knowledge and Perceptions of Individual Transition Planning and Its Process. Journal for Vocational Special Needs Education. Spr. 2007;29(3):13-21. X-4.
3663 Willis C. Young Children with Autism Spectrum Disorder: Strategies that Work. Young Children. 01. 2009;64(1):84-89. 81. 82. X-1, X-2, X-3, X-4.
3664 Wilson S. On seeing and not seeing. Journal of Child Psychotherapy. 08. 1994;20(2):165-184. X-1, X-3, X-4, X-10.
3665 Wilson TW, Rojas DC, Reite ML, et al. Children and adolescents with autism exhibit reduced MEG steady-state gamma responses. Biol Psychiatry. 08. 1. 2007;62(3):192-7. X-4. [pmid: 16950225].
3666 Wilson WH. Diagnostic consultation to a state hospital. Hosp Community Psychiatry. 12. 1989;40(12):1290-3. X-1, X-4, X-10. [pmid: 2591885].
3667 Wilson WH. Reassessment of state hospital patients diagnosed with schizophrenia. J Neuropsychiatry Clin Neurosci. Fall. 1989;1(4):394-7. X-1, X-4, X-10. [pmid: 2521089].
3668 Wimpory D. Mental handicap nursing. Autism--breaking through the barriers. Nurs Times. 08. 21–27. 1991;87(34):58-61. X-1, X-2, X-3, X-4, X-10.
3669 Wimpory D, Chadwick P, Nash S. Brief report: musical interaction therapy for children with autism: an evaluative case study with two-year follow-up. J Autism Dev Disord. 10. 1995;25(5):541-52. X-3, X-10. [pmid: 8567598].
3670 Wimpory DC, Nash S. Musical interaction therapy: Therapeutic play for children with autism. Child Language Teaching & Therapy. 02. 1999;15(1):17-28. X-3, X-10.
3671 Windsor J, Doyle SS, Siegel GM. Language acquisition after mutism: A longitudinal case study of autism. Journal of Speech & Hearing Research. 02. 1994;37(1):96-105. X-3, X-10. [pmid: 8170135].
3672 Wing L. Management of early childhood autism. Br J Hosp Med. 04. 355. 1981;25(4):353-6. 359. X-1, X-2, X-3, X-4, X-10. [pmid: 7236955].
3673 Wing L, Shah A. Catatonia in autistic spectrum disorders. Br J Psychiatry. 04. 2000;176:357-62. X-1, X-4. [pmid: 10827884].
3674 Winterling V, Dunlap G, O’Neill RE. The influence of task variation on the aberrant behaviors of autistic students. Education and Treatment of Children. 05. 1987;10(2):105-119. X-10.
3675 Winterling V, Gast DL, Wolery M, et al. Teaching safety skills to high school students with moderate disabilities. J Appl Behav Anal. Spring. 1992;25(1):217-27. X-1, X-3, X-4, X-10. [pmid: 1582967].
3676 Wire V. Autistic Spectrum Disorders and Learning Foreign Languages. Support for Learning. 08. 2005;20(3):123-128. X-1, X-2, X-3, X-4.
3677 Wirojanan J, Jacquemont S, Diaz R, et al. The efficacy of melatonin for sleep problems in children with autism, fragile X syndrome, or autism and fragile X syndrome. J Clin Sleep Med. 04. 15. 2009;5(2):145-50. X-3. [pmid: 19968048].
3678 Wishart JG, Cebula KR, Willis DS, et al. Understanding of Facial Expressions of Emotion by Children with Intellectual Disabilities of Differing Aetiology. Journal of Intellectual Disability Research. 07. 2007;51(7):551-563. X-1, X-4. [pmid: 17537169].
3679 Witwer A, Lecavalier L. Treatment incidence and patterns in children and adolescents with autism spectrum disorders. J Child Adolesc Psychopharmacol. 08. 2005;15(4):671-81. X-4. [pmid: 16190798].
3680 Wolery M. Commentary: the environment as a source of variability: implications for research with individuals who have autism. J Autism Dev Disord. 10. 2000;30(5):379-81. X-1, X-2, X-3, X-4. [pmid: 11098872].
3681 Wolery M, Barton EE, Hine JF. Evolution of Applied Behavior Analysis in the Treatment of Individuals With Autism. Exceptionality. 03. 2005;13(1):11-23. X-1, X-2, X-3, X-4.
3682 Wolery M, Gast DL, Kirk K, et al. Fading extra-stimulus prompts with autistic children using time delay. Education and Treatment of Children. 02. 1988;11(1):29-44. X-10.
3683 Wolf L, Goldberg B. Autistic children grow up: an eight to twenty-four year follow-up study. Can J Psychiatry. 08. 1986;31(6):550-6. X-1, X-4, X-10. [pmid: 3756758].
3684 Wolfberg PJ, Schuler AL. Integrated play groups: a model for promoting the social and cognitive dimensions of play in children with autism. J Autism Dev Disord. 09. 1993;23(3):467-89. X-3, X-10. [pmid: 8226582].
3685 Wolff S. Childhood autism: its diagnosis, nature, and treatment. Arch Dis Child. 06. 1991;66(6):737-41. X-1, X-2, X-3, X-4, X-10. [pmid: 2053803].
3686 Wong HH, Smith RG. Patterns of complementary and alternative medical therapy use in children diagnosed with autism spectrum disorders. J Autism Dev Disord. 10. 2006;36(7):901-9. X-4. [pmid: 16897395].
3687 Wong SE, Floyd J, Innocent AJ, et al. Applying a DRO schedule and compliance training to reduce aggressive and self-injurious behavior in an autistic man: A case report. Journal of Behavior Therapy and Experimental Psychiatry. 12. 1991;22(4):299-304. X-1, X-3, X-10. [pmid: 1823666].
3688 Wong SK, Tam SF. Effectiveness of a multimedia programme and therapist-instructed training for children with autism. Int J Rehabil Res. 12. 2001;24(4):269-78. X-3. [pmid: 11775031].
3689 Wong VC, Hui SL. Brief report: emerging services for children with autism spectrum disorders in Hong Kong (1960–2004). J Autism Dev Disord. 02. 2008;38(2):383-9. X-1, X-2, X-3, X-4. [pmid: 17605098].
3690 Wong VCN. Use of Complementary and Alternative Medicine (CAM) in Autism Spectrum Disorder (ASD): Comparison of Chinese and Western Culture (Part A). Journal of Autism and Developmental Disorders. 03. 2009;39(3):454-463. X-4. [pmid: 18784992].
3691 Wood AL, Luiselli JK, Harchik AE. Training instructional skills with paraprofessional service providers at a community-based habilitation setting. Behav Modif. 11. 2007;31(6):847-55. X-1, X-3, X-4. [pmid: 17932239].
3692 Wood BK, Wolery M, Kaiser AP. Treatment of Food Selectivity in a Young Child with Autism. Focus on Autism and Other Developmental Disabilities. 2009;24(3):169-177. X-3.
3693 Woodard C, Groden J, Goodwin M, et al. A placebo double-blind pilot study of dextromethorphan for problematic behaviors in children with autism. Autism. 01. 2007;11(1):29-41. X-3. [pmid: 17175572].
3694 Woodard C, Groden J, Goodwin M, et al. The Treatment of the Behavioral Sequelae of Autism with Dextromethorphan: A Case Report. Journal of Autism and Developmental Disorders. 08. 2005;35(4):515-518. X-3. [pmid: 16134036].
3695 Woods TS. The selective suppression of a stereotypy in an autistic child: A stimulus control approach. Behavioural Psychotherapy. 07. 1983;11(3):235-248. X-3, X-10.
3696 Woods TS. Generality in the verbal tacting of autistic children as a function of “naturalness” in antecedent control. J Behav Ther Exp Psychiatry. 03. 1984;15(1):27-32. X-3, X-10. [pmid: 6470154].
3697 Woods TS. Programming common antecedents: A practical strategy for enhancing the generality of learning. Behavioural Psychotherapy. 04. 1987;15(2):158-180. X-3, X-10.
3698 Worth S, Reynolds S. The Assessment and Identification of Language Impairment in Asperger’s Syndrome: A Case Study. Child Language Teaching & Therapy. 2008;24(1):55-71. X-3.
3699 Wright B, Brzozowski AM, Calvert E, et al. Is the presence of urinary indolyl-3-acryloylglycine associated with autism spectrum disorder?. Dev Med Child Neurol. 03. 2005;47(3):190-2. X-4. [pmid: 15739724].
3700 Wulffaert J, van Berckelaer-Onnes I, Kroonenberg P, et al. Simultaneous analysis of the behavioural phenotype, physical factors, and parenting stress in people with Cornelia de Lange syndrome. J Intellect Disabil Res. 07. 2009;53(7):604-19. X-1, X-3, X-4. [pmid: 19522789].
3701 Wymbs BT, Robb JA, Chronis AM, et al. Long-Term, Multimodal Treatment of a Child with Asperger’s Syndrome and Comorbid Disruptive Behavior Problems: A Case Illustration. Cognitive and Behavioral Practice. Sum. 2005;12(3):338-350. X-3.
3702 Wynne ME, Rogers JJ. Variables discriminating residential placement of severely handicapped children. Am J Ment Defic. 03. 1985;89(5):515-23. X-4, X-10. [pmid: 3158202].
3703 Xie F, Tan CH, Li SC. Are they being used safely? A retrospective cross-sectional tertiary health care survey of selective serotonin reuptake inhibitors prescribing practice in Singapore. Hum Psychopharmacol. 10. 2005;20(7):459-65. X-1, X-4. [pmid: 16158447].
3704 Xu MM, Sethi A, Glasgow GP. Dosimetry of small circular fields for 6-MeV electron beams. Med Dosim. Spring. 2009;34(1):51-6. X-1, X-3, X-4. [pmid: 19181256].
3705 Yahalom I. Infinity and the limits of the unconscious. Psychoanal Rev. 04. 1998;85(2):205-15. X-1, X-2, X-3, X-4, X-10. [pmid: 9658451].
3706 Yalaz K, Vanli L, Yilmaz E, et al. Phenylketonuria in pediatric neurology practice: a series of 146 cases. J Child Neurol. 11. 2006;21(11):987-90. X-1, X-4. [pmid: 17092471].
3707 Yalnizoglu D, Haliloglu G, Turanli G, et al. Neurologic outcome in patients with MRI pattern of damage typical for neonatal hypoglycemia. Brain Dev. 06. 2007;29(5):285-92. X-1, X-4. [pmid: 17158011].
3708 Yamada A, Suzuki M, Kato M, et al. Emotional distress and its correlates among parents of children with pervasive developmental disorders. Psychiatry Clin Neurosci. 12. 2007;61(6):651-7. X-1, X-4. [pmid: 18081627].
3709 Yamamoto Ji, Mochizuki A. Acquisition and functional analysis of manding with autistic students. Journal of Applied Behavior Analysis. Spr. 1988;21(1):57-64. X-3, X-10. [pmid: 3372403].
3710 Yang NK, Schaller JL, Huang T-A, et al. Enhancing Appropriate Social Behaviors for Children with Autism in General Education Classrooms: An Analysis of Six Cases. Education and Training in Developmental Disabilities. 12. 2003;38(4):405-416. X-3.
3711 Yang TR, Wolfberg PJ, Wu SC, et al. Supporting children on the autism spectrum in peer play at home and school: piloting the integrated play groups model in Taiwan. Autism. 12. 2003;7(4):437-53. X-3. [pmid: 14678682].
3712 Yarbrough E, Santat U, Perel I, et al. Effects of fenfluramine on autistic individuals residing in a state developmental center. J Autism Dev Disord. 09. 1987;17(3):303-14. X-10. [pmid: 3308829].
3713 Yarwood J, Moreton J. MMR: midwives’ guide to providing information for parents. RCM Midwives. 05. 2003;6(5):208-10. X-1, X-2, X-3, X-4. [pmid: 12929353].
3714 Yazaki N. Regression in schizophrenia and its therapeutic value. Jpn J Psychiatry Neurol. 03. 1992;46(1):71-98. X-1, X-4, X-10. [pmid: 1353128].
3715 Yazbak FE, Diodati CJ. Postpartum live virus vaccination: lessons from veterinary medicine. Med Hypotheses. 09. 2002;59(3):280-2. X-1, X-2, X-3, X-4. [pmid: 12208153].
3716 Yekebas EF, Bogoevski D, Honarpisheh H, et al. Long-term follow-up in small duct chronic pancreatitis: A plea for extended drainage by “V-shaped excision” of the anterior aspect of the pancreas. Ann Surg. 12. 2006;244(6):940-6. discussion 946–8. X-1, X-4. [pmid: 17122619].
3717 Yi JI, Christian L, Vittimberga G, et al. Generalized Negatively Reinforced Manding in Children with Autism. Analysis of Verbal Behavior. 2006;22:21-33. X-3.
3718 Yianni-Coudurier C, Darrou C, Lenoir P, et al. What clinical characteristics of children with autism influence their inclusion in regular classrooms?. J Intellect Disabil Res. 10. 2008;52(10):855-63. X-4. [pmid: 18627431].
3719 Yilmaz I, Birkan B, Konukman F, et al. Using a Constant Time Delay Procedure to Teach Aquatic Play Skills to Children with Autism. Education and Training in Developmental Disabilities. 06. 2005;40(2):171-182. X-3.
3720 Yirmiya N, Solomonica-Levi D, Shulman C, et al. Theory of mind abilities in individuals with autism, Down syndrome, and mental retardation of unknown etiology: the role of age and intelligence. J Child Psychol Psychiatry. 11. 1996;37(8):1003-14. X-4, X-10. [pmid: 9119934].
3721 Yoder PJ, Layton TL. Speech following sign language training in autistic children with minimal verbal language. J Autism Dev Disord. 06. 1988;18(2):217-29. X-10. [pmid: 3410812].
3722 Yokoyama K, Naoi N, Yamamoto J-i. Teaching Verbal Behavior Using the Picture Exchange Communication System (PECS) With Children With Autistic Spectrum Disorders. Japanese Journal of Special Education. 03. 2006;43(6):485-503. X-3.
3723 Yonkers KA, Gullion C, Williams A, et al. Paroxetine as a treatment for premenstrual dysphoric disorder. J Clin Psychopharmacol. 02. 1996;16(1):3-8. X-1, X-4, X-10. [pmid: 8834412].
3724 Yoo JH, Williams DC, Napolitano DA, et al. Rate-decreasing effects of the atypical neuroleptic risperidone attenuated by conditions of reinforcement in a woman with mental retardation. Journal of Applied Behavior Analysis. Sum. 2003;36(2):245-248. X-1, X-3, X-4. [pmid: 12858988].
3725 York A, von Fraunhofer N, Turk J, et al. Fragile-X syndrome, Down’s syndrome and autism: awareness and knowledge amongst special educators. J Intellect Disabil Res. 08. 1999;43(Pt 4):314-24. X-1, X-4, X-10. [pmid: 10466870].
3726 Yorke ED, Kassaee A, Lin LC, et al. Dosimetric comparison of centered and off-centered posterior neck electron fields. Med Dosim. Winter. 1998;23(4):284-7. X-1, X-3, X-4, X-10. [pmid: 9863727].
3727 Young JG, Cohen DJ, Shaywitz SE, et al. Assessment of brain function in clinical pediatric research: behavioral and biological strategies. Schizophr Bull. 1982;8(2):205-35. X-1, X-2, X-3, X-4, X-10. [pmid: 6180470].
3728 Young JM, Krantz PJ, McClannahan LE, et al. Generalized imitation and response-class formation in children with autism. Journal of Applied Behavior Analysis. Special Issue: Integrating basic and applied research. Win. 1994;27(4):685-697. X-10.
3729 Yuan TF, Hoff R. Mirror neuron system based therapy for emotional disorders. Med Hypotheses. 11. 2008;71(5):722-6. X-1, X-2, X-3, X-4. [pmid: 18703289].
3730 Yuill N, Strieth S, Roake C, et al. Brief report: designing a playground for children with autistic spectrum disorders--effects on playful peer interactions. J Autism Dev Disord. 07. 2007;37(6):1192-6. X-3. [pmid: 17063401].
3731 Yung A, Wong V, Yeung R, et al. Outcome measure for paediatric rehabilitation: use of the Functional Independence Measure for children (WeeFIM). A pilot study in Chinese children with neurodevelopmental disabilities. Pediatr Rehabil. 01–03. 1999;3(1):21-8. X-4, X-10. [pmid: 10367290].
3732 Zaak D, Sroka R, Khoder W, et al. Photodynamic diagnosis of prostate cancer using 5-aminolevulinic acid--first clinical experiences. Urology. 08. 2008;72(2):345-8. X-1, X-4. [pmid: 18405945].
3733 Zane T, Davis C, Rosswurm M. The Cost of Fad Treatments in Autism. Journal of Early and Intensive Behavior Intervention. 2008;5(2):44-51. X-1, X-2, X-3, X-4.
3734 Zanolli K, Daggett J. The effects of reinforcement rate on the spontaneous social initiations of socially withdrawn preschoolers. J Appl Behav Anal. Spring. 1998;31(1):117-25. X-4, X-10. [pmid: 9532755].
3735 Zanolli K, Daggett J, Adams T. Teaching preschool age autistic children to make spontaneous initiations to peers using priming. J Autism Dev Disord. 08. 1996;26(4):407-22. X-3, X-10. [pmid: 8863092].
3736 Zanolli K, Daggett J, Ortiz K, et al. Using rapidly alternating multiple schedules to assess and treat aberrant behavior in natural settings. Behav Modif. 07. 1999;23(3):358-78. X-3, X-10. [pmid: 10467889].
3737 Zappella M. Young autistic children treated with ethologically oriented family therapy. Family Systems Medicine. Spr. 1990;8(1):14-27. X-10.
3738 Zappella M. Early-onset Tourette syndrome with reversible autistic behaviour: a dysmaturational disorder. Eur Child Adolesc Psychiatry. 02. 2002;11(1):18-23. X-1, X-3, X-4. [pmid: 11942423].
3739 Zappella M, Chiarucci P, Pinassi D, et al. Parental bonding in the treatment of autistic behavior. Ethology & Sociobiology. 01. 1991;12(1):1-11. X-10.
3740 Zappia M, Annesi G, Nicoletti G, et al. Sex differences in clinical and genetic determinants of levodopa peak-dose dyskinesias in Parkinson disease: an exploratory study. Arch Neurol. 04. 2005;62(4):601-5. X-1, X-4. [pmid: 15824260].
3741 Zarcone JR, Hellings JA, Crandall K, et al. Effects of risperidone on aberrant behavior of persons with developmental disabilities: I. A double-blind crossover study using multiple measures. Am J Ment Retard. 11. 2001;106(6):525-38. X-3. [pmid: 11708938].
3742 Zaroff CM, Devinsky O, Miles D, et al. Cognitive and behavioral correlates of tuberous sclerosis complex. J Child Neurol. 11. 2004;19(11):847-52. X-1, X-2, X-3, X-4. [pmid: 15658788].
3743 Zaw FKM, Bates GDL, Murali V, et al. Catatonia, autism, and ECT. Developmental Medicine & Child Neurology. 12. 1999;41(12):843-845. X-1, X-3, X-4, X-10. [pmid: 10619284].
3744 Zentall SS, Zentall TR. Optimal stimulation: a model of disordered activity and performance in normal and deviant children. Psychol Bull. 11. 1983;94(3):446-71. X-10. [pmid: 6657825].
3745 Zercher C, Hunt P, Schuler A, et al. Increasing joint attention, play and language through peer supported play. Autism. 12. 2001;5(4):374-98. X-3. [pmid: 11777255].
3746 Zhang X, Ji CY. Autism and mental retardation of young children in China. Biomed Environ Sci. 10. 2005;18(5):334-40. X-4. [pmid: 16370317].
3747 Zhu J, Yin FF, Kim JH. Point dose verification for intensity modulated radiosurgery using Clarkson’s method. Med Phys. 08. 2003;30(8):2218-21. X-1, X-3, X-4. [pmid: 12945987].
3748 Zimmerman AW. Commentary: immunological treatments for autism: in search of reasons for promising approaches. J Autism Dev Disord. 10. 2000;30(5):481-4. X-1, X-2, X-3, X-4. [pmid: 11098888].
3749 Zimmerman RK, Wolfe RM, Fox DE, et al. Vaccine criticism on the World Wide Web. J Med Internet Res. 2005;7(2):e17. X-1, X-2, X-3, X-4. [pmid: 15998608].
3750 Zingale M, Belfiore G, Mongelli V, et al. Organization of a family training service pertaining to intellectual disabilities. Journal of Policy and Practice in Intellectual Disabilities. 03. 2008;5(1):69-72. X-1, X-4.
3751 Zingarelli G, Ellman G, Hom A, et al. Clinical effects of naltrexone on autistic behavior. Am J Ment Retard. 07. 1992;97(1):57-63. X-1, X-3, X-10. [pmid: 1497864].
3752 Zingerevich C, Greiss-Hess L, Lemons-Chitwood K, et al. Motor Abilities of Children Diagnosed with Fragile X Syndrome with and without Autism. Journal of Intellectual Disability Research. 01. 2009;53(1):11-18. X-4. [pmid: 18771512].
3753 Zirkel PA. What Does the Law Say?. TEACHING Exceptional Children. 05–06. 2008;40(5):73-75. X-1, X-2, X-3, X-4.
3754 Zirkel PA, Rose T. Scientifically Based Research and Peer-Reviewed Research under the IDEA: The Legal Definitions, Applications, and Implications. Journal of Special Education Leadership. 03. 2009;22(1):36-50. X-1, X-2, X-3, X-4.
3755 Zissermann L. The effects of deep pressure on self-stimulating behaviors in a child with autism and other disabilities. American Journal of Occupational Therapy. 06. 1992;46(6):547-551. X-3, X-10. [pmid: 1605299].
3756 Zoccolella S, dell’Aquila C, Abruzzese G, et al. Hyperhomocysteinemia in levodopa-treated patients with Parkinson’s disease dementia. Mov Disord. 05. 15. 2009;24(7):1028-33. X-1, X-4. [pmid: 19353704].
3757 Zoltak BB. Autism: recognition and management. Pediatr Nurs. 03–04. 1986;12(2):90-4. X-10. [pmid: 3634294].
3758 Zucker NL, Losh M, Bulik CM, et al. Anorexia Nervosa and Autism Spectrum Disorders: Guided Investigation of Social Cognitive Endophenotypes. Psychological Bulletin. 11. 2007;133(6):976-1006. X-1,X- 2, X-3, X-4. [pmid: 17967091].
3759 Zuddas A, Di Martino A, Muglia P, et al. Long-term risperidone for pervasive developmental disorder: efficacy, tolerability, and discontinuation. J Child Adolesc Psychopharmacol. Summer. 2000;10(2):79-90. X-1, X-3. [pmid: 10933118].
3760 Zwaigenbaum L, Bryson S, Lord C, et al. Clinical assessment and management of toddlers with suspected autism spectrum disorder: insights from studies of high-risk infants. Pediatrics. 05. 2009;123(5):1383-91. X-2. [pmid: 19403506].
3761 Zwaigenbaum L, Thurm A, Stone W, et al. Studying the Emergence of Autism Spectrum Disorders in High-Risk Infants: Methodological and Practical Issues. Journal of Autism and Developmental Disorders. 03. 2007;37(3):466-480. X-1, X-2, X-3, X-4. [pmid: 16897376].