# Evidence Tables

Tables are sorted by year, then last name of first author.

## 2010

Akhondzadeh et al. 2010

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Akhondzadeh et al. 2010 Country: Iran Practice setting: Academic Intervention setting: outpatient clinic Enrollment period: April 2007–April 2009 Funding: Tehran University of Medical Sciences Author industry relationship disclosures: NR Design: RCT (Double-blind, parallel group) | Intervention: Pentoxifylline + risperidone or placebo + risperidone for 10 weeks Risperidone titration:; - up to 2 mg/day in children weighing between 10–40 kg (0.5 mg starting dosage with 0.5 mg increments in weekly dosage for first 3 weeks); - 3 mg/day for children >40 kg; Pentoxiphylline titration:; - 400 mg/day increase for children weighing between 10–40 kg (200 mg starting dose with 100 mg increments every 2 days); - 600 mg (300mg starting dose with 100 mg increments every 2 days) for children >40 kg.; Placebo:; - matched for shape, size, color and taste; Assessments: Aberrant Behavior Checklist- Community (ABC-C), Extrapyramidal Symptoms Rating Scale (ESRS) Groups: G1: pentoxifylline + risperidone G2: placebo + risperidone Co-interventions held stable during treatment: NR (no psychosocial therapies during trial) | Inclusion criteria:; - Between 4 and 12 years of age; - Met DSM-IV-TR criteria for Autistic Disorder; - Outpatients from a specialty clinic for children at a psychiatric teaching hospital; Exclusion criteria:; - concomitant schizophrenia or psychotic disorders; - history of drug or alcohol abuse; - history of tardive dyskinesia; - received neuroleptics or other psychotropic drug 6 months prior to recruitment; - significant active medical problem; - severe or profound mental retardation precluding definitive diagnosis of autism; Age, mean/yrs ± SD (range): G1: 8.05 ± 2.01 (4–11) G2: 7.37 ± 2.41 (4–12) Mental age: NR Gender: M, n (%): G1: 15 (75) G2: 14 (70) F, n (%): G1: 5 (25) G2: 6 (30) Race/ethnicity: NR SES: NR Diagnostic approach: Referral and confirmed In study by child psychiatrist | Social skills: ABC-C Lethargy/Social Withdrawal, mean ± SD: G1: 18.27 ± 2.97 G2: 17.29 ± 3.23 Communication/language: ABC-C Inappropriate Speech, mean ± SD: G1: 5.13 ± 0.83 G2: 4.94 ± 0.92 Repetitive behavior: ABC-C Stereotypic Behavior, mean ± SD: G1: 8.01 ± 1.30 G2: 7.72 ± 1.44 Problem behavior: ABC-C Hyperactivity/noncompliance, mean ± SD: G1: 16.03 ± 2.60 G2: 15.44 ± 2.88 ABC-C Irritability, mean ± SD: G1: 16.67 ± 2.71 G2: 16.06 ± 3.00 | Social skills: ABC-C Lethargy/Social Withdrawal, mean ± SD: G1: Week 10: 8.03 ± 3.64 G2: Week 10: 13.05 ± 1.93 G1 and G2 significantly different based on groups × time interaction (P ≤ 0.0001) Communication/language: ABC-C Inappropriate Speech, mean ± SD: G1: Week 10: 2.08 ± 0.94 G2: Week 10: 3.73 ± 0.55 G1 and G2 significantly different based on groups × time interaction (P ≤ 0.0001)
| Frequency of contact during study: every 2 weeks for 10 weeks Concomitant therapies, n (%): NR N at enrollment: G1: 20 G2: 20 N at follow-up: G1: 20 G2: 20 | Diagnostic tool/method: DSM-IV-TR score ≥6, clinical judgment, behavioral observation and semistructured interview with parent Diagnostic category, n (%): Autism: 40 (100) Other characteristics: Weight/kg, mean ± SD (range): G1: 27.90 ± 6.07 (20–41) < 30 kg: 17(85) > 30 kg: 3(15) G2: 26.75 ± 6.85 (15–39) < 30 kg: 17(85) > 30 kg: 3(15) History of previous medications, n (%): G1: Risperidone: 12 (6) Haloperidol: 2 (1) G2: Risperidone: 13 (65) Haloperidol: 3 (15) | | Repetitive behavior: ABC-C Stereotypic Behavior, mean ± SD: G1: Week 10: 3.57 ± 1.61 G2: Week 10: 5.59 ± 0.82 G1 and G2 significantly different based on groups × time interaction (P ≤ 0.0001) Problem behavior: ABC-C Hyperactivity/Non compliance, mean ± SD: G1: Week 10: 8.92 ± 4.05 G2: Week 10: 12.59 ± 1.86 G1 and G2 significantly different based on groups × time interaction (P ≤ 0.0001) ABC-C Irritability, mean ± SD: G1: Week 10: 7.14 ± 3.23 G2: Week 10: 11.65 ± 1.72 G1 and G2 significantly different based on groups-by-time interaction (P ≤ 0.0001)
| | | | Extrapyramidal Symptoms Rating Scale, n (%): G1: 7 (35) G2: 8(40) No significant difference found between groups. Harms, n (%): Constipation: G1: 3 (15) G2: 2 (10) P = 1.00 Restlessness: G1: 2 (10) G2: 2 (NR) P = 1.00 Day time drowsiness: G1: 6 (30) G2: 4 (20) P = 0.71 Gassing: G1: 3 (15) G2: 1 (5) P = 0.34 Increased appetite: G1: 8 (40) G2: 5 (25) P = 0.50 Weight gain: G1: 8 (40) G2: 7 (35) P = 1.00 Dry mouth: G1: 2 (10) G2: 3 (15) P = 1.00 Fatigue: G1: 3 (15) G2: 5 (25) P = 0.69 Loss of appetite: G1: 1 (5) G2: 3 (15) P = 0.60
| | | | No statistically significant difference found between groups Modifiers NR

Dawson et al., 2010

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Dawson et al., 2010 Country: US Practice setting: Academic Intervention setting: Home Enrollment period: NR Funding: NIH Author industry relationship disclosures: 2 of 8 Early Start Denver Model for Young Children with Autism (royalties) Design: RCT | Intervention: Early Start Denver Model: 20 hrs/week of ESDM, parent training, parent delivery for ≥ 5 hrs/week of ESDM, community services chosen by parents Assess-and-monitor: Families given resource manuals, intervention recommendations, and referrals for intervention at baseline and 2 follow-up assessments Duration: 2 years Frequency: 2 hour sessions, twice per day, 5 days/week Assessments: ADI-R; ADOS; MSEL (fine motor, visual reception, expressive language and receptive language scales); VABS; RBS Yearly assessments conducted by University of Washington examiners blind to group status for both groups (G1 & G2) and by community providers (G2) Groups: G1: Early Start Denver Model G2: assess-and-monitor Provider:; - Bachelor’s level therapists supervised by PhD level clinician with consultation from Clinical psychologist Speech-language pathologist Developmental behavioral pediatrician Occupational therapist; Measure of treatment fidelity reported: Yes | Inclusion criteria:; - Age < 30 months at intake; - Met criteria for autistic disorder on the Toddler Autism Diagnostic Interview; - Met ADOS criteria for autism or ASD; - Clinical diagnosis based on DSM-IV criteria using all available information; - Resides within 30 minutes of the University of Washington; - Willingness to participate in ≥ 2 year intervention; Exclusion criteria:; - Neurodevelopmental disorder of known etiology (such as fragile x syndrome); - Significant sensory or motor impairment; - Major physical problems such as a chronic serious health condition; - Seizures at time of entry; - Use of psychoactive medications; - History of a serious head injury and/or neurologic disease; - Alcohol or drug exposure during the prenatal period; - Ratio IQ below 35 as measured by mean age equivalence score/chronological age on the visual reception and fine motor subscales of the MSEL; Age, months ± SD: G1: 23.9 ± 4.0 G2: 23.1 ± 3.9 G1/G2: P = 0.490 Mental age: NR Gender, male-to-female ratio: 3.5:1 | Overall ratings: ADOS severity score, mean ± SD: G1: 7.2 ± 1.7 G2: 6.9 ± 1.7 G1/G2: P = 0.557 Social skills: VABS socialization score, mean ± SD: G1: 73.8 ± 7.7 G2: 72.4 ± 9.4 G1/G2: P = 0.594 IQ or Early Learning Composite Score: MSEL scale score, mean ± SD: Early-learning composite: G1: 61.0 ± 9.2 G2: 59.4 ± 8.6 G1/G2: P = 0.530 Receptive language: G1: 21.1 ± 4.7 G2: 21.2 ± 3.8 G1/G2: P = 0.920 Expressive language: G1: 24.5 ± 7.2 G2: 26.0 ± 8.6 G1/G2: P = 0.492 Visual reception: G1: 33.2 ± 11.0 G2: 30.8 ± 8.9 G1/G2: P = 0.406 VABS communication score, mean ± SD: G1: 68.4 ± 7.6 G2: 69.6 ± 7.3 G1/G2: P = 0.577 Repetitive Behavior: RBS total score, mean ± SD: G1: 15.2 ± 10.8 G2: 21.5 ± 19.2 G1/G2: P = 0.171 | Overall ratings: ADOS severity score, 2 years, mean ± SD: G1: 7.0 ± 1.9 G2: 7.3 ± 1.8 G1/G2: P = 0.422 Diagnostic category, 2 years, n: Autism: G1: 16 G2: 20 PDD-NOS: G1: 8 G2: 1 Social skills: VABS socialization score, 2 years, mean ± SD: G1: 69.2 ± 11.6 G2: 63.1 ± 9.3 G1/G2: P = 0.263 IQ or Early Learning Composite Score: MSEL scale score, 2 years, mean ± SD: Early-learning composite: G1: 78.6 ± 24.2 G2: 66.3 ± 15.3 G1/G2: P = 0.044 Receptive language: G1: 40.0 ± 16.3 G2: 31.5 ± 10.6 G1/G2: P = 0.048 Expressive language: G1: 36.6 ± 13.6 G2: 30.0 ± 9.2 G1/G2: P = 0.033 Visual reception: G1: 41.0 ± 17.9 G2: 34.5 ± 13.0 G1/G2: P = 0.433
| Co-interventions held stable during treatment: Yes Concomitant therapies: NR N at enrollment: G1: 24 G2: 24 N at follow-up (%): Year one: G1: 24 (100) G2: 23 (96) Year two: G1: 24 (100) G2: 21 (88) | Race/ethnicity, %: Asian: 12.5 White: 72.9 Latino: 12.5 Multiracial: 14.6 SES: Maternal education: NR Household income: NR Diagnostic approach: Referral and confirmed in study Diagnostic tool/method: Toddler Autism Diagnostic Interview, ADOS, DSM-IV Diagnostic category, n: Autism: G1: 21 G2: 18 PDD-NOS: G1: 3 G2: 6 Other characteristics: NR | Adaptive behavior: VABS adaptive behavior composite score, mean ± SD: G1: 69.5 ± 5.7 G2: 69.9 ± 7.3 G1/G2: P = 0.844 VABS daily living skills score, mean ± SD: G1: 87.3 ± 11.4 G2: 86.8 ± 10.0 G1/G2: P = 0.381 Motor skills: MSEL fine motor score, mean ± SD: G1: 33.9 ± 11.9 G2: 30.6 ± 10.7 G1/G2: P = 0.318 VABS motor skills score, mean ± SD: G1: 70.9 ± 6.2 G2: 72.5 ± 6.5 G1/G2: P = 0.862 | Communication/language: VABS communication score, 2 years, mean ± SD: G1: 82.1 ± 21.8 G2: 69.4 ± 15.8 G1/G2: P = 0.015 Repetitive behavior: RBS total score, 2 years, mean ± SD: G1: 16.7 ± 13.1 G2: 22.0 ± 16.3 G1/G2: P = 0.545 Adaptive behavior: VABS adaptive behavior composite score, 2 years, mean ± SD: G1: 68.7 ± 15.9 G2: 59.1 ± 8.8 G1/G2: P = 0.011 VABS daily living skills score, 2 years, mean ± SD: G1: 64.7 ± 12.4 G2: 58.0 ± 8.1 G1/G2: P = 0.013 Motor skills: MSEL fine motor score, 2 years, mean ± SD: G1: 33.5 ± 12.2 G2: 28.5 ± 9.5 G1/G2: P = 0.503 VABS motor skills score, 2 years, mean ± SD: G1: 77.4 ± 19.8 G2: 64.1 ± 12.3 G1/G2: P = 0.009
| | | | Harms: NR Modifiers: NR

Frankel et al., 2010

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Frankel et al., 2010 Country: US Practice setting: Academic Intervention setting: School and home Enrollment period: September 2003 to March 2008 Funding: NIH Author industry relationship disclosures: NR Design: Case series | Intervention: Children’s Friendship Training: children were integrated into classes being conducted by the UCLA Children’s Friendship Program, with no more than 4 children with ASD admitted to any class (class size was usually 10). Each training class was composed of children separated by no more than one grade level. Study children were not identified in any way to other class participants. Treatment consisted of 12 weekly sessions, each 60 minutes in length. Children and their parents were seen concurrently in separate locations (except for the finalization of the child’s homework assignment). Each child session (except the first and last) was composed of four segments:; - Children reported the results of their homework assignment (10 minutes); - Didactic presentation and brief, coached behavioral rehearsal between two children (20 minutes); - Coached play in which children practiced newly learned skills (25 minutes); - Parents and children were reunited and finalized homework contracts.; Number of sessions attended, mean ± SD: G1: 11.3 ± 0.8 G2: 10.7 ± 1.9 | Inclusion criteria:; - Satisfied ADOS-G and ADI-R criteria for ASD; - Currently attending a 2^nd^ through 5^th^ grade regular classroom for most of the school day without a “shadow” or other closely supervising adult; - Not currently prescribed any psychotropic medication; - Verbal IQ > 60; - Able to switch topics in conversation when the other person was interested in talking about something else; - Had adequate knowledge of rules in playing at least two common age- appropriate board games; - Knowledge of rules to play common school yard games; - Absence of a thought disorder; - Free of clinical seizure disorder, gross neurologic disease, or other medical disorders; Exclusion criteria:; - See inclusion criteria; Age, months ± SD: G1: 103.2 ± 15.2 G2: 101.5 ± 15.0 Mental age: WISC-III Verbal IQ, mean ± SD: G1: 106.9 ± 19.1 G2: 100.5 ± 15.7 Gender, n (%): Male: G1: 30 (85.7) G2: 28 (84.8) | Social skills: Loneliness scale score, mean ± SD: G1: 34.3 ± 12.3 G2: 37.8 ± 14.3 (n=32) Loneliness scale score, follow-up group, mean ± SD: G1: 36.3 ± 12.2 PHS popularity score, mean ± SD: G1: 7.2 ± 3.0 G2: 6.8 ± 3.00 PHS popularity score, follow-up group, mean ± SD: G1: 6.9 ± 3.0 Quality of Play Questionnaire score, mean ± SD: Host: G1: 2.4 ± 2.2 G2: 1.8 ± 2.3 (n=29) Guest: G1: 1.3 ± 1.6 G2: 1.1 ± 2.0 (n=29) Conflict: G1: 4.8 ± 4.2 G2: 5.1 ± 5.2 (n=27) Engage: G1: 4.2 ± 2.2 G2: 4.3 ± 2.1 (n=27) Disengage: G1: 5.2 ± 2.5 G2: 5.2 ± 2.2 (n=27) Quality of Play Questionnaire score, follow-up group, mean ± SD: Host: G1: 2.0 ± 2.1 Guest: G1: 1.4 ± 1.7 Conflict: G1: 4.3 ± 3.3 | Social Skills: Loneliness scale score, mean ± SD: G1: 31.4 ± 8.5 G2: 38.9 ± 13.3 (n=32) G1/G2: P < 0.025 Loneliness scale score, follow-up group, mean ± SD: Post-treatment: G1: 31.6 ± 8.1 12 weeks: G1: 33.0 ± 13.7 G1/BL: P = NS G1/PT: P = NS PHS popularity score, mean ± SD: G1: 8.0 ± 2.8 G2: 6.4 ± 2.9 G1/G2: P < 0.025 PHS popularity score, follow-up group, mean ± SD: Post-treatment: G1: 7.9 ± 2.7 12 weeks: G1: 7.4 ± 2.8 G1/BL: P = NS G1/PT: P = NS Quality of Play Questionnaire score, mean ± SD: Host: G1: 3.7 ± 1.7 G2: 1.4 ± 2.0 (n=29) G1/G2: P < 0.0001
| Homework required social contacts with children who were not class members Assessments: Children/parents in the intervention group completed outcome measures at baseline (just prior to receiving the intervention), the last night of the intervention, and at 12 week follow-up; waitlist controls completed outcome measures at baseline, 12 weeks later just prior to starting the intervention, and the last night of the intervention. Children and parents completed assessment measures in the presence of the research team, while teachers were mailed assessment measures at each of the testing periods. Child outcome measures: Loneliness Scale, PHS; parent measures: Quality of Play Questionnaire, SSRS; teacher measures: PEI; at baseline, WISC-III; VABS survey form; Socioeconomic Status Groups: G1: children’s friendship training intervention G2: children’s friendship training after 12 weeks; delayed treatment control Provider:; - Psychologist; - L.C.S.W.; - Undergraduate psychology students; Measure of treatment fidelity reported: Yes Co-interventions held stable during treatment: NR Concomitant therapies: NR | Female: G1: 5 (14.3) G2: 5 (15.2) Race/ethnicity, n (%): White: 45 (66.2) Asian: 10 (14.7) African American: 7 (10.3) Hispanic: 4 (5.9) Pacific Islander: 1 (1.4) Native American: 1 (1.4) SES: Hollingshead index, mean ± SD: G1: 44.6 ± 10.6 G2: 50.6 ± 11.8 (n=32) Household income: NR Diagnostic approach: In Study Diagnostic tool/method: ADOS-G and ADI-R; High Functioning ASSQ Diagnostic category, n: Autism: 68 PDD-NOS: 0 Aspergers: 0 Other characteristics, n (%): Completely mainstreamed: 61 (89.7) Special education classes (but included in a main- streamed recess and mainstream classroom for part of the school day): 6 (8.8) Mainstream classroom with special help for 1–2 hours a day: 1 (1.5) Grade, mean ± SD: G1: 3.2 ± 1.0 G2: 3.4 ± 1.2 | Engage: G1: 3.8 ± 2.1 Disengage: G1: 5.2 ± 2.3 SSRS score, mean ± SD: Assertion: G1: 9.5 ± 2.8 G2: 9.4 ± 3.4 Self-control: G1: 10.2 ± 3.4 G2: 9.0 ± 3.9 Externalizing: G1: 4.5 ± 2.6 G2: 5.4 ± 2.3 Internalizing: G1: 7.0 ± 1.7 G2: 7.2 ± 3.2 SSRS score, follow- up group, mean ± SD: Assertion: G1: 9.7 ± 2.8 Self control: G1: 9.8 ± 3.5 Externalizing: G1: 4.5 ± 2.4 Internalizing: G1: 7.1 ± 1.6 PEI score, mean ± SD: Withdrawal: G1: 4.0 ± 2.1 (n=31) G2: 3.8 ± 2.1 (n=28) Aggression: G1: 1.3 ± 1.7 (n=31) G2: 1.4 ± 1.8 (n=28) PEI score, follow-up group, mean ± SD: Withdrawal: G1: 4.2 ± 2.2 Aggression: G1: 1.5 ± 1.8 High functioning ASSQ, mean ± SD: G1: 22.4 ± 7.3 G2: 22.0 ± 9.3 | Guest: G1: 2.0 ± 2.5 G2: 1.2 ± 1.5 (n=29) G1/G2: P = NS Conflict: G1: 1.9 ± 2.8 G2: 3.3 ± 3.2 (n=29) G1/G2: P = 0.069 Engage: G1: 4.7 ± 2.2 G2: 4.3 ± 1.7 (n=29) G1/G2: P = NS Disengage: G1: 2.3 ± 1.7 G2: 4.8 ± 2.1 (n=29) G1/G2: P < 0.0001 Quality of Play Questionnaire score, follow-up group, mean ± SD: Post-treatment: Host: G1: 4.0 ± 1.6 Guest: G1: 1.8 ± 2.6 Conflict: G1: 1.8 ± 3.0 Engage: G1: 4.5 ± 2.2 Disengage: G1: 2.1 ± 1.6 12 weeks: Host: G1: 3.1 ± 2.9 G1/BL: P = NS G1/PT: P < 0.05 Guest: G1: 1.9 ± 1.5 G1/BL: P = NS G1/PT: P = NS Conflict: G1: 2.0 ± 2.6 G1/BL: P = NS G1/PT: P < 0.0005
| N at enrollment:^*^ G1: 35 G2: 33 N at follow-up: G1: 26 G2: 31 | | VABS score, mean ± SD: Communication: G1: 84.3 ± 20.5 (n=34) G2: 79.8 ± 15.3 Daily living: G1: 67.0 ± 18.2 (n=34) G2: 62.4 ± 15.7 Socialization: G1: 66.3 ± 10.8 (n=34) G2: 66.1 ± 10.8 Composite: G1: 68.1 ± 16.4 (n=34) G2: 64.4 ± 11.0 | Engage: G1: 4.2 ± 2.0 G1/BL: P = NS G1/PT: P = NS Disengage: G1: 4.1 ± 2.2 G1/BL: P < 0.0001 G1/PT: P < 0.025SSRS score, mean ± SD: Assertion: G1: 11.8 ± 3.2 G2: 10.5 ± 3.2 G1/G2: P = 0.054 Self-control : G1: 12.2 ± 2.9 G2: 10.1 ± 3.7 G1/G2: P < 0.05 Externalizing: G1: 3.8 ± 2.1 G2: 5.2 ± 2.3 G1/G2: P = 0.062 Internalizing: G1: 6.4 ± 2.1 G2: 7.3 ± 2.5 G1/G2: P = 0.058 SSRS score, follow-up group, mean ± SD: Post-treatment: Assertion: G1: 11.7 ± 2.8 Self Control: G1: 12.0 ± 2.8 Externalizing: G1: 3.8 ± 2.0 Internalizing: G1: 6.2 ± 1.7 12 weeks: Assertion: G1: 12.0 ± 3.5 G1/BL: P = NS G1/PT: P < 0.0001 Self Control: G1: 11.8 ± 3.8 G1/BL: P = NS G1/PT: P < 0.005
| | | | Externalizing: G1: 3.8 ± 2.5 G1/BL: P = NS G1/PT: P = NS Internalizing: G1: 6.0 ± 2.5 G1/BL: P = NS G1/PT: P < 0.025PEI score, mean ± SD: Withdrawal: G1: 3.6 ± 2.4 (n=31) G2: 3.7 ± 2.1 (n=28) G1/G2: P = NS Aggression: G1: 1.0 ± 1.3 (n=31) G2: 1.4 ± 2.0 (n=28) G1/G2: P = NS PEI score, follow- up group, mean ± SD: Post-treatment: Withdrawal: G1: 3.5 ± 2.5 Aggression: G1: 1.3 ± 1.3 12 weeks: Withdrawal: G1: 3.6 ± 2.8 G1/BL: P = NS G1/PT: P = NS Aggression: G1: 1.6 ± 1.7 G1/BL: P = NS G1/PT: P = NS Harms: NR Modifiers: NR

Comments:

* Initially, 40 children were assigned to G1 and 36 were assigned to G2 but 5 in G1 and 3 in G2 did not complete 12 week assessments and are not included in baseline data.

Golan et al. 2010

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Golan et al. 2010 Country: US (NY), Israel, UK Practice setting: Academic Medical Center Intervention setting: Home Enrollment period: NR Funding: NIHR CLAHRC and the NHS Foundation Trust Author industry relationship disclosures: NR Design: RCT | Intervention: “The Transporters,” a children’s animation series on DVD with eight vehicle characters moving according to rule-based motion; - intended to improve understanding and recognition of emotions in 3–8 yr old ASD children; - 15 five-minute episodes, focusing on a specific emotion or mental state (happy, sad, angry, afraid, disgusted, surprised, excited, tired, unfriendly, kind, sorry, proud, jealous, joking and ashamed); - includes quizzes related to each episode; - parents given a guide to the DVD and encouraged to help child to internalize and apply learned material to other situations; Exposure to DVD or standard school curriculum over a period of 4 weeks, participants tested before (Time 1) and after (Time 2) intervention Assessments: ADI-R, Children’s Autism Spectrum Test (CAST), British Picture Vocabulary Scale (BPVS), emotional vocabulary, situation- facial expression matching (SEM) task Emotion recognition tasks were conducted on computer using PowerPoint beginning with Level 1 with 16 questions at each level | Inclusion criteria:; - Met Autism Development Index – Revised (ADI-R) and Children’s Autism Spectrum Test (CAST) criteria for autism spectrum disorder; Exclusion criteria:; - For typical control group only - no history of learning difficulties, neurological, or psychiatric disorders, or close relations with ASD; Age, mean/yrs ± SD (range): G1: 5.6 ± 1.0 (4–7) G2: 6.2 ± 1.0 (4–8) G3: 5.4 ± 1.1 (4–7) Mental age: NR Gender: M, n (%): G1: 15 G2: 15 G3: 12 F, n (%): G1: 5 G2: 4 G3: 6 Race/ethnicity: NR SES: NR Diagnostic approach: In Study & Referral Diagnostic tool/method: In-Study: ADI-R & CAST for G1; CAST for G2; CAST for G3 Referral: G1 & G2 diagnosed in specialist centers using American Psychiatric Association established criteria | Overall ratings: CAST, mean ± SD (range): G1: 24.0 ± 6.2 (15– 33) G2: 24.1 ± 5.4 (17– 33) G3: 6.3 ± 3.2 (2–12) Communication/language: Verbal ability, mean ± SD (range): G1: 98.3 ± 10.7 (76–116) G2: 99.4 ± 7.9 (86– 111) G3: 103.3 ± 7.8 (89–115) Emotional Vocabulary, mean ± SD: (max = 16) G1: 8.25 ± 2.81 G2: 9.17 ± 3.62 G3: 12.50 ± 2.26 Situation-Expression Matching tasks (SEM) Levels 1–3, mean ± SD: SEM-Level 1: (max = 16) G1: 8.65 ± 2.54 G2: 9.67 ± 2.57 G3: 11.94 ± 1.73 SEM-Level 2: (max = 16) G1: 9.80 ± 2.91 G2: 9.33 ± 2.91 G3: 12.72 ± 2.30 SEM-Level 3: (max = 16) G1: 9.85 ± 2.43 G2: 9.67 ± 2.77 G3: 13.00 ± 2.28 | Communication/language: Emotional Vocabulary, score, mean ± SD: (max = 16) G1: 12.50 ± 3.09 G2: 9.11 ± 3.45 G3: 13.06 ± 2.49 Group: P < 0.01 Time: P < 0.001 Group × time: P < 0.001 Situation- Expression Matching tasks (SEM) Levels 1–3, mean ± SD: SEM-Level 1: (max = 16) G1: 13.00 ± 2.45 G2: 8.94 ± 2.34 G3: 12.39 ± 2.09 Group: P < 0.01 Time: P < 0.001 Group × time: P < 0.001 SEM-Level 2: (max = 16) G1: 13.45 ± 2.35 G2: 9.22 ± 2.69 G3: 12.94 ± 1.59 Group: P < 0.001 Time: P < 0.001 Group × time: P < 0.001 SEM-Level 3: (max = 16) G1: 13.30 ± 2.27 G2: 9.61 ± 2.83 G3: 12.89 ± 1.78 Group: P < 0.001 Time: P < 0.001 Group × time: P < 0.001 G1 improved significantly from Time 1 to Time 2 on all four tasks (P < 0.001)
| Groups: G1: ASD children given Transporters DVD intervention, at least 3 episodes per day for 4 weeks G2: ASD children with no intervention (standard school curriculum) G3: typically developing controls with no intervention Provider: Parental supervision during DVD viewing session Treatment manual followed: NR Defined protocol followed: yes Measure of treatment fidelity reported: yes Co-interventions held stable during treatment: NR Concomitant therapies, n (%): NR N at enrollment: G1: 20 G2: 19 G3: 18 N at follow-up: G1: 20 G2: 18 G3: 18 | Diagnostic category, n (%): Autism: G1: 20 (51) G2: 19 (49) G3: 0 Other characteristics: Days between assessments, mean ± SD (range) G1: 28.8 ± 3.3 (24–38) G2: 28.2 ± 3.8 (22–37) G3: 27.8 ± 1.4 (25–31) | | Harms: NR Modifiers: Positive correlation between verbal ability and improvement on the Level 2 SEM in G1 (r = 0.58, P < 0.01); positive correlation between verbal ability and improvement on the Emotional Vocabulary task in G3 (r = 0.57, P < 0.02). No other significant correlations between age, verbal ability, time between two assessment meetings and improvement scores for each task.

Green et al. 2010

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Green et al. 2010 Country: UK (London, Manchester and Newcastle) Practice setting: Specialty treatment center Intervention setting: Clinic, home Enrollment period: September 2006 through February 2008 Funding: University of Manchester, Medical Research Council; UK Department for Children, Schools and Families; UK Department of Health Design: RCT See related study Aldred et al. 2004 | Intervention: Parent-mediated communication-focused (Preschool Autism Communication Trial [PACT]) intervention or treatment as usual at three specialist centers After an initial orientation meeting, families attended biweekly 2-hr clinic sessions for 6 mos followed by monthly booster sessions for 6 mos (total=18). Between sessions, families were also asked to do 30 min of daily home practice. Families in both groups of the trial continued with treatment as usual. Follow-up at 13 mos. Assessments: ADOS, PLS, MCDI, CSBS-DP, & VABS Groups: G1: Preschool Autism Communication Trial (PACT) and treatment as usual G2: Treatment as usual Provider:; - Speech and language therapists; Treatment manual followed: Yes Defined protocol followed: Yes Measure of treatment fidelity reported: Yes Co-interventions held stable during treatment: NR | Inclusion criteria:; - Met criteria for core autism according to ADOS-G and ADI-R; - Age 2 yrs to 4 yrs and 11 mos; Exclusion criteria:; - Twin with autism; - Non-verbal age ≤12 mos on the Mullen Early Learning Scales; - Epilepsy requiring medication; - Severe hearing or visual impairment in a parent or the child; - Parent with a severe psychiatric disorder requiring treatment; Age, mean months (range): G1: 45 (26–60) G2: 45 (24–60) Mental age, mean months ± SD: Mullen non-verbal IQ age equivalent: G1: 27.0 ± 10.0 G2: 25.3 ± 9.5 Gender: n (%): M: G1: 71 (92) G2: 67 (89) F: G1: 6 (8) G2: 8 (11) Parents’ race/ethnicity, n (%): White: G1: 46 (60) G2: 41 (55) 1 white, 1 non-white: G1: 5 (6) G2: 9 (12) Non-white: G1: 26 (34) G2: 25 (33) | ADOS-G total social-communication algorithm score, mean ± SD: G1: 19.6 ± 4.2 G2: 19.3 ± 4.0 ADOS-G social domain, mean ± SD: G1: 10.7 ± 2.2 G2: 10.7 ± 2.1 ADOS-G communication domain, mean ± SD: G1: 8.9 ± 2.5 G2: 8.6 ± 2.5 ADOS-G repetitive behavior domain, mean ± SD: G1: 3.7 ± 1.5 G2: 3.7 ± 1.4 Preschool Language Scales (PLS) receptive raw scores, mean ± SD: G1: 15.6 ± 9.8 G2: 15.0 ± 9.7 PLS expressive raw scores, mean ± SD: G1: 15.0 ± 8.1 G2: 15.1 ± 7.9 Parent-child interaction: parental synchrony, mean % ± SD: G1: 31.8 ± 14.8 G2: 31.3 ± 14.6 Parent-child interaction: child initiations, mean % ± SD: G1: 23.0 ± 17.4 G2: 24.4 ± 18.5 | Change in ADOS-G diagnosis to autism spectrum disorder, n (%): G1: 22 (30) G2: 17 (24) Change in ADOS-G diagnosis to non-spectrum, n (%): G1: 4 (5) G2: 5 (7) Analysis adjusted for initial ADOS-G category, age group, and center: nonsignificant effect of treatment on any clinician-or teacher-rated outcomes Social skills: ADOS-G, total social-communication algorithm score, mean ± SD: G1: 15.7 ± 6.0 G2: 16.5 ± 5.7 Change from baseline, mean ± SD: G1: −3.9 ± 4.7 G2: −2.9 ± 3.9 ADOS-G social domain, mean ± SD: G1: 9.2 ± 3.0 G2: 9.8 ± 2.9 Change from baseline, mean ± SD: G1: −1.5 ± 2.8 G2: −0.9 ± 2.5
| Concomitant therapies, n (%): Contact time with other treatment professionals, mean hours ± SD: G1: 9.5 ± 16.3 G2: 9.8 ± 12.9 Group-based autism psychoeducation, n (%): G1: 28 (38) G2: 34 (49) Communication-focused interventions, n (%): G1: 27 (36) G2: 23 (33) Early intensive behavioral intervention, n: G1: 1 G2: 0 Son-Rise therapy, n: G1: 1 G2: 0 Portage, n: G1: 10 G2: 10 Special educational needs setting, n (%): G1: 30 (41) G2: 24 (34) Education setting with specific provisions for ASD, n (%): G1: 8 (11) G2: 10 (14) Speech & language therapy: Mean hrs ± SD: G1: 9.5 ± 16.3 /case G2: 9.8 ± 12.9 /case N at enrollment: G1: 77 G2: 75 N at follow-up: G1: 74 G2: 72 | SES: Education (one parent with qualifications after age 16 years), n (%): G1: 65 (84) G2: 47 (63) Household income: NR SES (dichotomized as at least one parent in professional or administrative occupation versus all others), n (%): G1: 51 (66) G2: 44 (59) Diagnostic approach: In Study Diagnostic tool/method:; - Social and communication domains of the ADOS-G; - Two of three domains of the ADI-R; Diagnostic category, n (%): Core autism: 152 (100) Other characteristics: NR | Parent-child interaction: shared attention time, mean % ± SD: G1: 65.3 ± 22.0 G2: 67.0 ± 21.9 ADI-R, mean (range): Reciprocal social interaction: G1: 17.9 (9–25) G2: 18.2 (8–26) Restricted, repetitive, and stereotyped patterns: G1: 5.2 (0–10) G2: 5.6 (0–10) Non-verbal communication: G1: 10.7 (3–14) G2: 11.0 (3–14) Verbal communication: G1 (n=22): 15.7 (9–21) G2 (n=25): 15.7 (10–23) ADOS-G, mean (range): Module 1 (at most single words) (G1: n=60; G2: n=57) Communication: G1: 6.3 (4–8) G2: 6.1 (4–8) Reciprocal social interaction: G1: 10.9 (7–14) G2: 10.8 (7–14) Module 2 (phrase speech) (G1: n=17; G2: n=18) Communication: G1: 6.6 (5–9) G2: 6.7 (5–9) | Parent-child interaction: parental synchrony, mean % ± SD: G1: 51.3 ± 19.6 G2: 32.6 ± 14.0 Change from baseline, mean % ± SD: G1: 19.5 ± 21.3 G2: 1.4 ± 15.3 Parent-child interaction: child initiations, mean % ± SD: G1: 34.9 ± 19.7 G2: 26.0 ± 17.5 Change from baseline, mean % ± SD: G1: 11.9 ± 25.6 G2: 1.6 ± 21.4 Parent-child interaction: shared attention time, mean % ± SD: G1: 64.0 ± 25.7 G2: 55.6 ± 25.7 Change from baseline, mean % (SD): G1: −1.4 ± 23.7 G2: −11.4 ± 28.4 Analysis adjusted for center, age group, sex, verbal ability, nonverbal ability, socioeconomic status, and education qualifications were 2.28 (95% CI 0.17 – 4.39) for CSBS-DP social composite scores;
| | | Reciprocal social interaction: G1: 9.1 (6–12) G2: 9.7 (6–14) Module 1 and 2 restricted and repetitive behavior: G1: 3.7 (0–6) G2: 3.7 (1–6) Parent-rated Communication and Symbolic Behavior Scales Development Profile (CSBS-DP), mean ± SD: G1: 29.5 ± 7.1 G2: 28.3 ± 8.8 Parent-rated MacArthur Communicative Development Inventory (MCDI), mean ± SD: Receptive raw score: G1: 159.5 ± 114.4 G2: 162.0 ± 122.4 Expressive raw score: G1: 93.5 ± 114.8 G2: 111.1 ± 128.6 | Communication/language: ADOS-G communication domain, mean (SD): G1: 6.6 (3.3) G2: 6.7 (3.2) Change from baseline, mean (SD): G1: −2.3 (2.6) G2: −1.9 (2.4) PLS receptive raw scores, mean (SD) G1: 21.5 (13.0) G2: 20.3 (12.8) Change from baseline, mean (SD): G1: 6.0 (6.7) G2: 5.3 (5.9) PLS expressive raw scores G1: 20.0 (11.2) G2: 20.0 (11.3) Change from baseline, mean (SD): G1: 5.1 (5.6) G2: 4.9 (5.2) Parent-rated CSBS-DP, mean (SD): G1: 34.0 (8.2) G2: 30.8 (8.3) Change from baseline, mean (SD): G1: 4.6 (7.0) G2: 2.5 (6.0) Parent-rated MCDI receptive raw score, mean (SD): G1: 233.7 (129.6) G2: 209.0 (131.3) Change from baseline, mean (SD): G1: 74.2 (66.9) G2: 47.0 (68.2)
| | | | Parent-rated MCDI expressive raw score, mean mean (SD): G1; 171.9 (150.7) G2: 163.8 (144.3) Change from baseline, mean (SD): G1: 78.5 (89.3) G2: 51.8 (73.2) Analysis adjusted for center, age group, sex, verbal ability, nonverbal ability, socioeconomic status, and education qualifications were 30.28 (95% CI 6.90–53.68) for MCDI receptive scores; analysis of MCDI expressive scores nonsignificant Teacher-rated Vineland communication score, mean (SD): G1: 64.3 (17.7) G2: 67.7 (17.5) Repetitive behavior: ADOS-G repetitive behavior domain, mean (SD): G1: 3.0 (1.7) G2: 3.5 (1.6) Change from baseline, mean (SD): G1: −0.7 (1.9) G2: −0.2 (1.6) Problem behavior: NR
| | | | Adaptive behavior: Teacher-rated Vineland Adaptive behavior composite, mean (SD): G1: 60.3 (15.2) G2: 62.8 (14.8) Commonly occurring comorbidities: NR Medical: NR Motor skills: NR Sensory: NR Educational/cognitive/academic attainment: NR Harms NR Modifiers No effect of age, baseline autism severity, nonverbal ability or SES on intervention effect Significant treatment by Center interactions for Parental synchrony (P = 0.005), child initiations (P = 0.06). Smallest treatment differences noted in Manchester.

Munasinghe et al. 2010

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Munasinghe et al. 2010 Country: Australia Practice setting: Academic medical center Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: Randomized, double-blind, placebo-controlled cross-over trial | Intervention: Proteolytic enzyme supplement (Peptizyde) Sequence 1: supplement for 3 months, then 1 week wash-out period, followed by placebo for 3 months; Sequence 2: placebo for 3 months, then 1 week washout period, followed by supplement for 3 months; Treatment: ½ to 1 capsule with the largest meal of the day, increasing over several days to 2 capsules with each meal. Maximum dosage: ≤9 capsules per day. Placebo: rice bran 235 mg, beet root fiber 125 mg per capsule Unused capsule returned to pharmacists and documented Assessments: Global Behaviour Rating Scale (GBRS), Additional Rating Scale (ARS), Language Development Survey (LDS), Therapist Rating Scale Groups: G1: proteolytic enzyme supplement /placebo G1a: supplement phase G1b: placebo phase G2: placebo/proteolytic enzyme supplement G2a: placebo phase G2b: supplement phase Co-interventions held stable during treatment: Any behavioral or medical therapy begun ≥ 3 months prior to study was continued without interruption | Inclusion criteria:; - aged 3–8 years; - resident in the Perth metropolitan area; - must meet DSM-IV criteria for Autistic Disorder or Pervasive Developmental Disorder, Not Otherwise Specified; - parent must agree to avoid starting any other alternative therapies for the child during the study; Exclusion criteria:; - significant hearing or vision loss; - co-morbid neurological disorders including phenylketonuria, tuberous sclerosis, neurofibromatosis, other identifiable metabolic disorders, genetic abnormalities or intractable seizure disorders,; - any new medical/surgical intervention in the next 6 months or within a week of a scheduled surgery; - history of allergy to Aspergillus enzyme proteins or papaya or any known allergy to fungal proteins; - active stomach or duodenal ulcers or severe bowel inflammation (blood in stool), celiac disease; - history of hemophilia or other bleeding disorders; Age, mean/mos ± SD (range): G1: 68.57 ± 21.28 (34–101) G2: 70.14 ± 23.66 (36–104) Mental age: NR | NR | Social skills: GBRS, therapist engagement score, mean ± SD: G1a+G2b: 4.59 ± 0.96 G1b+G2a: 4.43 ± 0.55 P = 0.49 Generalized estimating equation (GEE) comparison of treatment to placebo: P = 0.91 Communication/language: LDS Vocabulary score, percentile ± SD: G1a+G2b: 56.95 ± 28.6 G1b+G2a: 55.59 ± 28.6 P = 0.17 GEE comparison of treatment to placebo: P = 0.09 LDS Sentence length score, percentile ± SD: G1a+G2b: 62.38 ± 26.2 G1b+G2a: 63.91 ± 24.9 P = 0.55 GEE comparison of treatment to placebo: P = 0.42 Problem behavior: GBRS, Parent behavior score, mean ± SD: G1a+G2b: 4.29 ± 0.79 G1b+G2a: 4.11 ± 0.73 P = 0.38 GEE comparison of treatment to placebo: P = 0.28
| Frequency of contact during study: Monthly Concomitant therapies, %: Alternative therapy(kinesiology, herbal and homeopathic products): G1: 33 G2: 27 Prescription medication (methylphenidate, clonidine, sodium valproate, risperidone, trimeprazine tartrate, dexchlorpheniramine, inhaled cromolyn, salbutamol, fluticasone proprionate, topical corticosteroids, laxatives): G1: 43 G2: 45 Special diet (gluten and casein free, gluten free, organic foods only, egg-free and low sugar): G1: 10 G2: 27 Multivitamins: G1: 14 G2: 14 N at enrollment: G1: 21 G2: 22 N at follow-up: G1: 11 G2: 16 | Gender: M, %: G1: 86 G2: 82 F, %: G1: 14 G2: 18 Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: DSM IV Diagnostic category, %: Autism: G1: 90 G2: 86 PDD-NOS: G1: 10 G2: 14 Other characteristics: NR | | Commonly occurring comorbidities: ARS, Food variety score, mean ± SD: G1a+G2b: 4.42 ± 0.62 G1b+G2a: 4.06 ± 0.45 P = 0.02 GEE comparison of treatment to placebo: P = 0.02 ARS, Gastrointestinal symptoms score, mean ± SD: G1a+G2b: 4.01 ± 0.68 G1b+G2a: 3.87 ± 0.36 P = 0.34 GEE comparison of treatment to placebo: P = 0.41 Sleep quality score, mean ± SD: G1a+G2b: 3.95 ± 0.75 G1b+G2a: 3.87 ± 0.56 P = 0.61 GEE comparison of treatment to placebo: P = 0.74 Harms No serious effects reported ; 2 children withdrawn by parents due to increased irritability, aggression, inattentiveness (1 on treatment, 1 on placebo); problems persisted after treatment discontinuation
| | | | 2 children withdrawn from study due to irritability and difficulty engaging in the classroom (authors note changing family and school environment issues on follow-up) Modifiers No significant effect of Use of alternative therapies, multivitamins, prescription medication or special diets on enzyme effect size in GEE model

Owley et al., 2010

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Owley et al., 2010 Country: US Practice setting: Academic clinic Intervention setting: Academic medical center Enrollment period: NR Funding: NIH, Autism Speaks Author industry relationship disclosures: NR Design: Prospective case series | Intervention: 10-week open label study of escitalopram based on genotype group, with participants seen at clinic at study start (baseline), week 4, and week 10. Forced titration with weekly increasing doses of escitalopram (2.5, 5, 10, 15, 20mg) unless specific criteria for downward titration due to side effects were met. Assessments: ABC-C completed weekly by parents/caregivers Groups: G1: all participants G1a: Low expression of serotonin transporter polymorphism promoter region (5-HTTPLR) genotypic variation (9 S/S) G1b: Intermediate expression (1 L_G_/L_G_, 2 S/L_G_, 2 L_A_/L_G_, 24 S/L) G1c: High expression (19 L_A_/L_A_) Co-interventions held stable during treatment: NR Frequency of contact during study: NR Concomitant therapies: Participants ceased psychoactive medication use 1 month prior to study; participants previously on fluoxetine stopped medication 6 weeks prior to study. N at enrollment: G1: 58^*^ G1a: 9 G1b: 29 G1c: 19 | Inclusion criteria:; - Diagnosis of an ASD; - Minimum score of 12 on the ABC-CV; Exclusion criteria:; - Parental sleep diaries during pre-medication baseline week indicating a range in time of awakening greater than 2 hours over 7 days; - Concomitant serious medical or psychiatric conditions, including seizures; - Study personnel unable to obtain blood sample due to child’s restlessness (n=1); - Dropout (n=1); Age, mean months ± SD (range): G1: 117 ± 31 (54–204) G1a: 124 ± 22 (98–164) G1b: 121 ± 34 (82–204) G1c: 106 ± 28 (54–160) Mental age: NR Gender, n (%): G1: M: 48 (83) F: 10 (17) G1a: M: 8 (89) F: 1 (11) G1b: M: 25 (86) F: 4 (14) G1c: M: 14 (74) F: 5 (26) | ADI-R, mean ± SD (range): G1: Social interaction: 23 ± 5 (11–30) Communication, verbal: 17 ± 4 (7–26) Communication, non-verbal: 13 ± 2 (10–15) Repetitive behavior: 6 ± 3 (1–15) Abnormality of development: 4 ± 1 (1–5) G1a: Social interaction: 24 ± 4 (18–29) Communication, verbal: 18 ± 5 (11–26) Communication, non-verbal: 13 ± 1 (13–14) Repetitive behavior: 6 ± 2 (2–9) Abnormality of development: 4 ± 1 (2–5) G1b: Social interaction: 24 ± 4 (14–30) Communication, verbal: 17 ± 4 (10–23) Communication, non-verbal: 12 ± 2 (10–15) Repetitive behavior: 7 ± 3 (2–12) Abnormality of development: 4 ± 1 (0–5) G1c: Social interaction: 23 ± 5 (11–30) Communication, verbal: 17 ± 4 (7–26) Communication, non-verbal: 13 ± 2 (10–15) Repetitive behavior: 6 ± 3 (1–15) | Problem behavior: Final data on ABC Irritability subscale scores only represented graphically. Harms NR Modifiers Final dose did not differ significantly between genotype groups. Age and weight were not significantly correlated with final dose in the whole group or in the genotype expression subgroups.
| N at follow-up: G1: 45 G1a: NR G1b: NR G1c: NR *1 participant with rare genotype excluded from subgroup analyses | Race/ethnicity, n (%): G1: African American: 6 (10) Asian: 2 (3) Caucasian: 48 (83) Hispanic: 2 (3) G1a: African-American: 1 (11) Asian: 1 (11) Caucasian: 7 (78) Hispanic: 0 G1b: African-American: 5 (17) Asian: 1 (3) Caucasian: 21 (72) Hispanic: 2 (7) G1c: African-American: 0 Asian: 0 Caucasian: 19 (100) Hispanic: 0 SES: Maternal education: NR Household income: NR Diagnostic approach: In Study: ADI-R, ADOS Diagnostic tool/method: ADI-R, Autism Diagnostic Observation Schedule, cognitive testing, psychiatric evaluation Diagnostic category (best estimate diagnosis), n (%): G1: Autistic disorder: 35 (60) PDD-NOS: 17 (29) Asperger’s: 6 (10) G1a: Autistic disorder: 6 (67) PDD-NOS: 1 (11) Asperger’s: 2 (22) G1b: Autistic disorder: 20 (69) PDD-NOS: 7 (24) Asperger’s: 2 (7) G1c: Autistic disorder: 8 (42) PDD-NOS: 9 (47) Asperger’s: 2 (11) | Abnormality of development: 4 ± 1 (1–5) ADOS, mean±SD (range): G1: Social interaction: 9 ± 3 (4–14) Communication: 5 ± 2 (2–10) Communication+ social: 15 ± 4 (7–23) Play: 2 ± 1 (0–4) Stereotyped behavior/interests: 3 ± 2 (0–6) G1a: Social interaction: 9 ± 3 (4–14) Communication: 5 ± 2 (3–8) Communication+ social: 15 ± 5 (7–22) Play: 2 ± 1 (0–4) Stereotyped behavior/interests: 3 ± 2 (0–6) G1b: Social interaction: 10 ± 3 (4–14) Communication: 5 ± 2 (2–10) Communication+ social: 15 ± 5 (7–23) Play: 2 ± 1 (0–4) Stereotyped behavior/interests: 3 ± 2 (0–6) G1c: Social interaction: 9 ± 3 (4–14) Communication: 5 ± 2 (2–10) Communication+ social: 15 ± 4 (7–23) Play: 2 ± 1 (0–4) Stereotyped behavior/interests: 3 ± 2 (0–6)
| | Other characteristics: NR | Non-verbal IQ, mean ± SD (range): G1: 86 ± 34 (21–146) G1a: 63 ± 34 (21–103) G1b: 91 ± 33 (25–140) G1c: 86 ± 34 (21–146) Verbal IQ, mean ± SD (range):: G1: 76 ± 35 (11–141) G1a: 60 ± 36 (11–114) G1b: 75 ± 34 (14–141) G1c: 76 ± 35 (11–141) ABC Irritability scale score, mean ± SD (range):: G1: 21 ± 6 (12–37) G1a: 21 ± 5 (14–30) G1b: 20 ± 6 (12–33) G1c: 21 ± 6 (12–37) ABC Hyperactivity scale score, mean ± SD (range):: G1: 25 ± 11 (4–45) G1a: 22 ± 8 (10–36) G1b: 27 ± 10 (7–45) G1c: 25 ± 11 (4–45)
Author: Pan 2010 Country: Taiwan Practice setting: University Intervention setting: School Enrollment period: NR Funding: Grant from National Science Council, Taiwan Design: Prospective case series | Intervention: Water exercise swimming program (WESP), 10 weeks, 20 sessions (two sessions/week, 90 minutes each) for improvement of aquatic and social skills Duration: 21 weeks, with 10 weeks WESP, 10 weeks control, and 1 week transition Assessments: School Social Behavior Scales (SSBS-2) completed by classroom teacher Baseline (T1), after 10 weeks (T2) and after 20 weeks (T3). Classroom teachers were blinded to children’s treatment conditions. HAAR checklist used to assess aquatic skills Groups: G1a: WESP for first 10 weeks followed by 10 weeks regular treatment/activity G1b: regular treatment/activity for first 10 weeks then WESP for second 10 weeks Provider:; - 4 research assistants completed WESP training course prior to study and served as swimming instructors; Treatment manual followed: Yes Defined protocol followed: Yes Measure of treatment fidelity reported: No | Inclusion criteria:; - Diagnosis of mild ASD or Asperger syndrome; - Age 6–9 years; - Able to follow instructions; - Parental commitment to allow participation without changing current therapy or activity; Exclusion criteria:; - Intellectual disability; Age, mean/yrs ± SD (range): G1a: 7.27 ± 1.25 (5.58–9.75) G1b: 2 7.20 ± 0.89 (6.08–8.58) Mental age, mean/yrs (range): NR Gender, n (%): M: 16 (100) F: 0 (0) Race/ethnicity, n (%): Asian: 16 (100) SES: Maternal education: NR Household income: NR All described as residing in urban setting with two- parent household Diagnostic approach: Referral (diagnosis by medical and psychological assessment by physicians in the public hospitals) Diagnostic tool/method: DSM-IV Diagnostic category, n (%): Mild or high-functioning autism: 8 (50) Aspergers: 8 (50) | Social skills: SSBS-2, mean ± SD: Peer relations: G1a: 41.50 ± 4.17 G1b: 43.00 ± 4.57 Social competence total: G1a: 42.67 ± 3.02 G1b: 43.38 ± 4.31 Adaptive behavior: SSBS-2, mean ± SD: Self- management/compliance: G1a: 44.13 ± 2.17 G1b: 44.38 ± 3.74 Educational/cognitive/academic attainment: SSBS-2, mean ± SD: Academic behavior, mean: G1a: 45.88 ± 2.30 G1b: 45.25 ± 6.30 Problem behavior: SSBS-2, mean ± SD: Hostile/irritable, mean: G1a: 60.38 ± 5.24 G1b: 60.75 ± 6.20 Antisocial/aggressive, mean: G1a: 52.00 ± 3.30 G1b: 56.00 ± 7.60 Defiant/disruptive: G1a: 59.50 ± 5.15 G1b: 58.63 ± 7.41 Antisocial behavior total: G1a: 58.00 ± 4.17 G1b: 59.38 ± 6.93 | T2: after 10 weeks of WESP or regular/treatment/ activity T3: after an additional 10 weeks Adaptive behavior: T2: SBSS-2, mean ± SD: Self- management/compliance: G1a: 47.13 ± 4.88 G1b: 45.13 ± 4.32 T3: SBSS-2, mean ± SD: Self- management/compliance: G1a: 46.38 ± 6.57 G1b: 50.75 ± 4.46 Educational/cognitive/academic attainment: T2: SBSS-2, mean ± SD: Academic behavior: G1a: 51.38 ± 2.20^*^ G1b: 48.50 ± 4.21 T3: Academic behavior: G1a: 50.38 ± 2.45 G1b: 52.75 ± 4.03 Social skills: T2: SBSS-2, mean ± SD: Peer relations: G1a: 43.88 ± 4.92 G1b: 41.63 ± 5.26
Author: Pan 2010 Country: Taiwan Practice setting: University Intervention setting: School Enrollment period: NR Funding: Grant from National Science Council, Taiwan Design: Prospective case series | Co-interventions held stable during treatment: Yes Concomitant therapies, n (%): Occupational therapy: 6 (37.5) Physical therapy: 2 (12.5) Group therapy: 3 (18.75) Speech therapy: 1 (6.25) Community-based physical activity program: 4 (25) Ritalin for ADD symptoms: 2 (12.5) N at enrollment: G1a: 8 G1b: 8 N at follow-up: G1a: 8 G1b: 8 | Both groups were split 4/4 for high-functioning autism and asperger syndrome Other characteristics: Height, mean/cm ± SD: G1a: 128.75 ± 7.83 G1b: 124.43 ± 4.04 Weight, mean kg ± SD: G1a: 30.54 ± 8.73 G1b: 25.59 ± 5.77 BMI mean kg/m^2^ ± SD: G1a: 18.27 ± 4.32 G1b: 16.40 ± 2.80 | Motor skills: HAAR, mean ± SD: HAAR stage 1- mental adjustment: G1a: 95 ± 9.26 G1b: 100 ± 0 HAAR stage II-intro to water: G1a: 51.25 ± 15.53 G1b: 58.75 ± 13.56 HAAR Stage III- rotations: G1a: 0 ± 0 G1b: 4.16 ± 11.77 HAAR Stage IV- balance & controlled movement: G1a: 25 ± 9.45 G1b: 32.81 ± 17.60 HAAR Stage V- independent movement in water: G1a: 0 ± 0 G1b: 8.33 ± 15.41 | Social competence total: G1a: 46.25 ± 3.99 G1b: 43.88 ± 3.48 T3: SBSS-2, mean ± SD: Peer relations: G1a: 45.50 ± 5.45 G1b: 47.13 ± 3.44 Social competence total: G1a: 46.50 ± 5.07 G1b: 49.63 ± 3.11^**^ Problem behavior: T2: SBSS-2, mean ± SD: Hostile/irritable: G1a: 46.25 ±5.18^*^ G1b: 53.25 ± 7.89 Antisocial/aggressive: G1a: 45 ± 4.44^*^ G1b: 48.75 ± 7.07 Defiant/disruptive: G1a: 45.88 ± 6.47^*^ G1b: 51.63 ± 7.23 Antisocial behavior total: G1a: 45.75 ± 5.44^*^ G1b: 51.75 ± 7.38 T3: SBSS-2, mean ± SD: Hostile/irritable: G1a: 53.25 ± 7.72^**^ G1b: 43.75 ± 2.92^**^ Antisocial/aggressive: G1a: 48.75 ± 5.73 G1b: 44.75 ± 2.76
Author: Pan 2010 Country: Taiwan Practice setting: University Intervention setting: School Enrollment period: NR Funding: Grant from National Science Council, Taiwan Design: Prospective case series | | | | Defiant/disruptive: G1a: 51.75 ± 8.19 G1b: 45 ± 4.54 Antisocial behavior total: G1a: 51.63 ± 7.35 G1b: 44 ± 2.73^**^ *P < 0.01 compared to baseline (T1) within groups **P < 0.01 compared to T2 Motor skills: HAAR, mean ± SD: T2: HAAR stage 1- mental adjustment: G1a: 100 ± 0 G1b: 100 ± 0 T3: G1a: 100 ± 0 G1b: 100 ± 0 HAAR stage II- intro to water: T2: G1a: 90 ± 11.95 (P < 0.01 compared to T1, P < 0.01 compared to G1b) G1b: 58.75 ± 13.56 T3: G1a: 86.28 ± 17.68 G1b: 87.50 ± 14.88 (P < 0.01 compared to T2)
Author: Pan 2010 Country: Taiwan Practice setting: University Intervention setting: School Enrollment period: NR Funding: Grant from National Science Council, Taiwan Design: Prospective case series | | | | HAAR Stage III- rotations: T2: G1a: 33.33 ± 25.21 (P < 0.01 compared to T1, P < 0.01 compared to G1b) G1b: 4.16 ± 11.77 T3: G1a: 33.33 ± 25.21 G1b: 20.83 ± 24.80 HAAR Stage IV- balance & controlled movement: T2: G1a: 71.88 ± 17.36 (P < 0.01 compared to T1, P < 0.01 compared to G1b) G1b: 32.81 ± 17.60 T3: G1a: 71.88 ± 17.36 G1b: 68.75 ± 18.90 (P < 0.01 compared to T2)
Author: Pan 2010 Country: Taiwan Practice setting: University Intervention setting: School Enrollment period: NR Funding: Grant from National Science Council, Taiwan Design: Prospective case series | | | | HAAR Stage V- independent movement in water: T2: G1a: 64.60 ± 18.78 (P < 0.01 compared to T1, P < 0.01 compared to G1b) G1b: 8.33 ± 15.41 T3: G1a: 64.60 ± 18.78 G1b: 52.08 ± 20.79 (P < 0.01 compared to T2) G1a: NS for differences between T2 and T3 G1b: NS for differences between T1 and T2 Harms NR Modifiers NR

Reed et al. 2010

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Reed et al. 2010 Country: England Practice setting: Academic Intervention setting: School, home Enrollment period: NR Funding: NR Design: Prospective cohort | Intervention: For a period of 1 year, children received one of three early teaching interventions: a 1:1 authority-provided home- based program (PACTS), a general special nursery for children with all types of learning difficulty, or an autistic special nursery for children only with ASDs. Special nurseries had eclectic interventions Intervention time (hours/week), mean ± SD: G1: 11.5 ± 6.0 G2: 16.3 ± 3.3 G3: 12.6 ± 2.3 Assessments: Psycho-Educational Profile-Revised (PEP-R); British Abilities Scale; Vineland Adaptive Behavior Scales; Gilliam Autism Rating Scale (GARS) Assessments were performed by an educational psychologist at the child’s home at baseline. The follow up assessments were performed by the same psychologist at the child’s home 9 months later. Groups: G1: General Special Nursery G2: Autistic Special Nursery G3: PACTS Provider: Psychologist Treatment manual followed: NR | Inclusion criteria:; - ages 2 years 6 months to 4 years 0 months at the start of their intervention; - Receiving no other major intervention during the period of the assessment; - Diagnosis of ASD given by an independent pediatrician; Exclusion criteria:; - See above; Age, mean/months ± SD: G1: 44.3 ± 4.8 G2: 42.8 ± 3.9 G3: 40.8 ± 5.6 Mental age: NR Gender, n (% of group): G1: M: 11 (92) F: 1 (8) G2: M: 7 (87.5) F: 1 (12.5) G3: M: 12 (92) F: 1 (8) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In Study Diagnostic tool/method: Independent pediatrician Diagnostic category: NR Other characteristics: Characteristics interventions: | Overall ratings: GARS autism quotient, mean ± SD: G1: 98.5 ± 11.6 G2: 95.9 ± 8.0 G3: 95.1 ± 11.6 Educational/cognitive/academic attainment: PEP–R overall, mean ± SD: G1: 47.7 ± 22.3 G2: 58.1 ± 15.5 G3: 49.3 ± 13.2 BAS cognitive ability, mean ± SD: G1: 55.0 ± 14.0 G2: 61.9 ± 10.2 G3: 52.4 ± 10.0 Adaptive behavior: Vineland composite, mean ± SD: G1: 51.1 ± 4.5 G2: 55.8 ± 3.5 G3: 56.2 ± 4.1 | Overall ratings: GARS change from baseline score, mean ± SD: G1: 2.2 ± 9.5 P > 0.40 G2: −5.9 ± 8.7 P > 0.09 G3: 1.6 ± 6.2 P > 0.30 Educational/cognitive/academic attainment: PEP–R overall score, mean ± SD: G1: 56.6 ± 24.1 P < 0.07, ES = 0.63 G2: 70.1 ± 16.3 P < 0.05, ES = 0.7 G3: 55.9 ± 21.5 P > 0.10, ES = 0.5 Educational functioning: BAS cognitive ability, mean ± SD: G1: 63.4 ± 16.2 P < 0.01 G2: 69.0 ± 14.9 P > 0.10 G3: 57.6 ± 12.6 P < 0.05 Adaptive behavior: Vineland composite, mean ± SD: G1: 54.2 ± 9.3 P > 0.10, ES = 1.2 G2: 59.3 ± 5.1 P < 0.05, ES = 0.8 G3: 55.8 ± 5.6) ES = −0.1
Author: Reed et al. 2010 Country: England Practice setting: Academic Intervention setting: School, home Enrollment period: NR Funding: NR Design: Prospective cohort | Measure of treatment fidelity reported: No Co-interventions held stable during treatment: Yes Concomitant therapies: No other major interventions during assessment period N at enrollment: G1: 12 G2: 8 G3: 13 N at follow-up: G1: 12 G2: 8 G3: 13 | Intervention hours/week, range: G1: 3–21 G2: 13–23 G3: 11–20 1:1 teaching, hours/week ± SD: G1: 2.6 ± 2.5 G2: 1.8 ± 1.0 G3: 12.2 ± 2.5 Group teaching, hours/week ± SD: G1: 8.9 ± 5.5 G2: 14.6 ± 2.6 G3: 0.5 ± 0.9 Tutors, mean n ± SD: G1: 2.83 ± 0.6 G2: 3.1 ± 0.6 G3: 3.1 ± 1.0 Family tutors, mean n ± SD: G1: 0.50 ± 0.9 G2: 0 G3: 0.6 ± 0.8 Service providers, n G1: 5 G2: 2 G3: 1 | | Significant improvements for 3 developmental age outcomes relative to baseline for all 3 groups were observed Harms: NR Modifiers: Relationship between overall gains and temporal input: G1 & G2: Posiitve (gains = 1.4 +0.3 hrs/week, r^2^ = 0.10) G3: Negative (gains = 18.1-0.50, r^2^ = 0.21)

Whalen et al., 2010

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Whalen et al., 2010 Country: US (CA) Practice setting: Specialized school program Intervention setting: Classroom Enrollment period: NR Funding: Agency/NR Design: RCT (randomized by classroom, no individual randomization) | Intervention: TeachTown: Basics is a computer-assisted intervention (CAI) with supplementary off- computer activities. This intervention was implemented for 3 months and consisted of 20 minutes/day on the computer and 20 minutes/day in supplementary activities. 8 classrooms in 4 schools were randomly assigned to standard teaching or to TeachTown: Basics. Groups: G1a: TeachTown: Basics Preschool, school 1 G1b: TeachTown: Basics K-1, school 1 G1c: TeachTown: Basics Preschool, school 2 G1d: TeachTown: Basics K-1, school 2 G2a: Control, Preschool, school 3 G2b: Control, K-1, school 3G2c: Control, Preschool, school 4 G2d: Control, K-1, school 4 Provider:; - Teacher; Treatment manual followed: No Defined protocol followed: Yes Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR | Inclusion criteria:; - Children aged 3–6 years with autism; - Attended Los Angeles Unified School District’s Intensive Comprehensive Autism Program (ICAP); Exclusion criteria: See inclusion criteria Age, in years (range): 3–6 Mental age: NR Gender: NR Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: NR Diagnostic tool/method: Diagnostic method NR; CARS administered by each child’s teacher for measurement of disease severity Diagnostic category, n (%): Autism: 47 (100) Other characteristics: NR | CARS score, mean: G1: 42 G1a: 33 G1b: 39 G1c: 44 G1d: 52 G2: 43 G2a: 45 G2b: 37 G2c: 45 G2d: 45 Peabody Picture Vocabulary Test (PPVT), mean: G1a+c: 8.82 G2a+c: 9.67 | Communication/language: PPVT, mean: G1a+c: 23.36 G2a+c: 14.92 P = 0.036 G1b+d vs. G2b+d (values NR): P = 0.577 EVT: (values NR) G1a+c vs. G2a+c: P = 0.444 G1b+d vs. G2b+d: P = 0.375 Brigance Inventory of Early Development (values NR) scores and subscores: no significant differences between G1 and G2 Significant correlation between number of lessons mastered in G1 with overall pre-post change in Brigance score (P = 0.042) Harms NR
| Concomitant therapies, n (%): G1: speech, language & occupational interventions delivered but values NR G2: none N at enrollment: G1: 22 G1a: 6 G1b: 5 G1c: 5 G1d: 6 G2: 25 G2a: 7 G2b: 5 G2c: 6 G2d: 7 N at follow-up: G1: 22 G1a: 6 G1b: 5 G1c: 5 G1d: 6 G2: 25 G2a: 7 G2b: 5 G2c: 6 G2d: 7 | | | Modifiers 15 children in G1 mastered lessons in the software program during the 3 month study period; no significant difference in Brigance scores between these children and the 7 G1 children who did not master a lesson. Significant correlation between time spent on the software and the total number of lessons mastered in G1 (P = 0.01)

## 2009

Adams et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Adams et al., 2009 (A) Adams et al., 2009 (B)† Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: None Design: RCT | Intervention: Phase I: Application of lotion that contained glutathione or placebo 1× per day after bath, with child rubbing it on for 7 days; all children received oral DMSA at 10 mg/kg 3× per day for 3 days Phase II: children then received either DMSA or placebo for up to 3 rounds (each round consisted of 3 days followed by 11 days of no DMSA/placebo); - Children who received glutathione lotion received DSMA, those who received placebo lotion received placebo in Phase II; - All participants received vitamin/mineral supplements for ≥ 2 months prior to and through the study period; Duration: NR Frequency: NR Assessments: Phase I: ATEC and Heavy Metal Exposure Questionnaire completed by parents at baseline Phase II: ADOS administered by clinician following the completion of Phase I (at onset and completion of Phase II); parent completed the PDD-BI and SAS (at onset and completion of Phase II); Parental Global Impressions questionnaire (post-treatment only, answers range from -3 “much worse” to +3 “much better”); clinician working with child to complete ATEC for the child (post- treatment only) | Inclusion criteria: Phase I:; - Age 3–8 years; - ASD, diagnosed by a psychiatrist, psychologist, or developmental pediatrician; - No mercury amalgam dental fillings; - No previous DMSA or other prescription chelators; - No anemia or currently being treated for anemia due to low iron; - No known allergies to DMSA; - No liver or kidney disease; - Well hydrated; Phase II:; - Excretion of high amounts of toxic metals in Phase I; - Normal liver function (serum transaminases ALT and AST), normal renal function, and complete blood cell count was not below the normal reference range; - No changes in medication, supplements, diet, or behavioral interventions during the study; - At least a two-month history of taking a multi- vitamin/mineral supplement with a least the RDA of zinc, and continuing to take that during Phase II; - Continue to stay well hydrated; Exclusion criteria:; - See inclusion criteria; Age, years:† G1: 6.7 G2: 6.5 Mental age: NR | Overall ratings: ATEC SPLC, mean ± SD: G1: 13.4 ± 7.7 G2: 12 ± 8.4 ATEC Total, mean ± SD: G1: 80.8 ± 24 G2: 66.2 ± 20.7 AWP/C composite (sensory + ritual + social pragmatic + semantic + arousal + fears + aggressive), mean ± SD: G1: 105 ± 58.6 (n=25) G2: 93.8 ± 29.5 REXSCA/C composite (social approach + express + LMRL), mean ± SD: G1: 127 ± 52.7 (n=25) G2: 135 ± 65.5 Autism composite (sensory + ritual + social problems – social approach behaviors – expressive language), mean ± SD: G1: −53.1 ± 66.4 (n=25) G2: −63.5 ± 65.1 SAS score, phase 1 onset, mean ± SD: G1: 5.2 ± 2.2) G2: 5.5 ± 2.7) Social skills: ATEC Sociability, mean ± SD: G1: 16.6 ± 8.5 G2: 14.9 ± 6.8 PDD-BI Social pragmatic problems, mean ± SD: G1: 16.9 ± 9.2 (n=25) G2: 13.9 ± 7.5 | Overall ratings: ATEC SPLC, mean ± SD: G1: 10.6 ± 7 G2: 10.5 ± 8.9 G1/BL: P < 0.001 G2/BL: P = NS ATEC Total, mean ± SD: G1: 60.14 ± 27.9 G2: 53.4 ± 23.5 G1/BL: P < 0.001 G2/BL: P < 0.01 AWP/C composite, mean ± SD: G1: 79.5 ± 49.9 G2: 71.6 ± 38.8 G1/BL: P < 0.001 G2/BL: P < 0.001 REXSCA/C composite: G1: 139 ± 54.5 G2: 150 ± 53.6 G1/BL: P < 0.01 G2/BL: P < 0.05 Autism composite: G1: −73.3 ± 67.9 G2: −88.8 ± 58.3 G1/BL: P < 0.01 G2/BL: P < 0.01 SAS score, completion of phase 2, mean ± SD: G1: 4.2 ± 2 G2: 4.5 ± 2.6 G1/BL: P < 0.001 G2/BL: P < 0.01 Social skills: ATEC Sociability, mean ± SD: G1: 12.1 ± 6.5 G2: 11.2 ± 6.5 G1/BL: P < 0.001 G2/BL: P < 0.05
| Groups: G1: treatment (7 rounds of treatment) G2: placebo (1 round of treatment followed by 6 rounds of placebo) Provider(s): NR Measure of treatment fidelity reported: Yes Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: Phase 1: 82 Phase 2 :49 N at follow-up: Phase 1: 65 G1: 26 G2: 15 | Gender, n:† Male: G1: 24 G2: 14 Female: G1: 2 G2: 1 Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: Initially diagnosed by community clinicians independent of this study, confirmed by ADOS- certified evaluator Diagnostic Tool: ADOS Diagnostic category, %:† Autism: G1: 96 G2: 100 Asperger’s: G1: 4 G2: 0 Other characteristics: NR | AWP/C Social approach behaviors, mean ± SD: G1: 63.8 ± 20.6 (n=25) G2: 68.2 ± 25.4 ADOS Sociability, mean: G1: 9.3 G2: 8.1 ADOS Communication + sociability, mean: G1: 17 G2: 14.7 Communication/language: PDD-BI Semantic/pragmatic problems: G1: 15.2 ± 7.6 n=25) G2: 11.1 ± 5.6 AWP/C Express (phonological + semantic pragmatic), mean ± SD: G1: 41.4 ± 28.2 (n=25) G2: 44 ± 34.9 AWP/C Learning, memory, and receptive language, mean ± SD: G1: 22.7 ± 8.1 (n=25) G2: 23.2 ± 10.1 ADOS Communication, mean: G1: 7.8 G2: 6.7 ADOS Communication + sociability, mean: G1: 17 G2: 14.7 | PDD-BI Social pragma-tic problems, mean ± SD: G1: 14.5 ± 9.2 G2: 9.9 ± 7.5 G1/BL: P = NS G2/BL: P < 0.01 AWP/C Social approach behaviors, mean ± SD: G1: 70.8 ± 23.6 G2: 72.6 ± 20.2 G1/BL: P < 0.01 G2/BL: P = NS ADOS Sociability, mean (% change): G1: 8.3 (−10) G2: 7.9 (−2) G1/BL: P < 0.01 G2/BL: P = NS ADOS Communication + sociability, mean (%change): G1: 15.4 (−9) G2: 13.7 (−7) G1/BL: P < 0.001 G2/BL: P = NS Communication/language: PDD-BI Semantic/pragmatic problems, mean ± SD: G1: 12.5 ± 7.3 G2: 9.6 ± 4.5 G1/BL: P = NS G2/BL: P = NS AWP/C Express, mean ± SD: G1: 43.6 ± 27.1 G2: 51.3 ± 31.5 G1/BL: P = NS G2/BL: P < 0.05
| | | Problem behavior: PDD-BI Ritualisms/resistance to change, mean ± SD: G1: 13.9 ± 10.5 (n=25) G2: 15 ± 8.5 PDD-BI Arousal regulation problems, mean ± SD: G1: 17.9 ± 9 (n=25) G2: 14.9 ± 6.6 PDD-BI Aggressiveness, mean ± SD: G1: 13.4 ± 9.8 (n=25) G2: 11.4 ± 8.1 Adaptive behavior: ATEC Health/physical behavior, mean ± SD: G1: 29.9 ± 14.4 G2: 21.5 ± 9.4 PDD-BI Specific fears, mean ± SD: G1: 21.7 ± 16 (n=25) G2: 18.7 ± 10.3 ADOS Play, mean: G1: 3.2 G2: 2.8 ADOS SBRI, mean: G1: 3.9 G2: 3.5 Sensory: ATEC Sensory/cognitive awareness, mean ± SD: G1: 16 ± 7.4 G2: 13 ± 6.8 PDD-BI Sensory/perceptual approach behaviors, mean ± SD: G1: 22.8 ± 14.7 (n=25) G2: 20 ± 13.6 | AWP/C Learning, memory, and receptive language, mean ± SD: G1: 25.4 ± 8.7 G2: 26.5 ± 8.9 G1/BL: P < 0.05 G2/BL: P < 0.01 ADOS Communication, mean (%change): G1: 7.1 (−9) G2: 5.9 (−11) G1/BL: P = NS G2/BL: P = NS ADOS Communication + sociability, mean (%change): G1: 15.4 (−9) G2: 13.7 (−7) G1/BL: P < 0.001 G2/BL: P = NS Problem behavior: PDD-BI Ritualisms/resistance to change, mean ± SD: G1: 10 ± 7.8 G2: 11.5 ± 8.2 G1/BL: P < 0.01 G2/BL: P < 0.01 PDD-BI Arousal regulation problems, mean ± SD: G1: 13.9 ± 8.5 G2: 12.1 ± 8.8 G1/BL: P < 0.01 G2/BL: P = NS PDD-BI Aggressiveness, mean ± SD: G1: 9.8 ± 6.7 G2: 8.4 ± 7.2 G1/BL: P < 0.05 G2/BL: P < 0.05
| | | | Adaptive behavior: ATEC Health/physical behavior, mean ± SD: G1: 21.6 ± 10.1 G2: 18.3 ± 9.2 G1/BL: P < 0.01 G2/BL: P = NS PDD-BI Specific fears, mean ± SD: G1: 14.6 ± 12.1 G2: 15.9 ± 11.1 G1/BL: P < 0.01 G2/BL: P = NS ADOS Play, mean (%change): G1: 3 (−5) G2: 2.8 (0) G1/BL: P = NS G2/BL: P = NS ADOS SBRI, mean (%change): G1: 3.5 (−9) G2: 3.5 (−2) G1/BL: P = NS G2/BL: P = NS Sensory: ATEC Sensory/cognitive awareness, mean ± SD: G1: 11.7 ± 7.9 G2: 9.6 ± 5.9 G1/BL: P < 0.001 G2/BL: P < 0.05 PDD-BI Sensory/perceptual approach behaviors, mean ± SD: G1: 17.8 ± 13.9 G2: 13.7 ± 13.4 G1/BL: P < 0.05 G2/BL: P < 0.01
| | | | Parent global impression, overall category, score, %:^**^ G1: +3 “much better”: G1: 29 G2: 27 +2 “better”: G1: 33 G2: 27 +1 “slightly better”: G1: 25 G2: 27 0 “no change”: G1: 4 G2: 18 −1 “slightly worse”: G1: 4 G2: 0 −2: “worse”: G1: 4 G2: 0 −3 “much worse”: G1: 0 G2: 0 Parent global impression, category, mean score:^**^ Parent global impression Overall: G1: 1.7 G2: 1.6 Parent global impression Expressive language G1: 2 G2: 1.6 Parent global impression Receptive language: G1: 1.8 G2: 1.9
| | | | Parent global impression Cognition/thinking G1: 1.8 G2: 1.8 Parent global impression Play skills: G1: 1.5 G2: 1.6 Parent global impression Sociability G1: 1.3 G2: 1.8 Parent global impression Eye contact: G1: 1.1 G2: .8 Parent global impression Tantruming: G1: 0.5 G2: 0.3 Parent global impression Stools/gastro- intestinal issues: G1: 0 G2: −0.2 Parent global impression Sleep: G1: −0.3 G2: −0.1 Parent global impression Hyperactivity: G1: −0.5 G2: −0.1 Harms:† Withdrew from phase 2 due to adverse events: G1: 2 G2: 2 Withdrew from phase 2 due to low urinary excretion of metals: G1: 2 G2: 0
| | | | Sleep problems, worsening of some behavior and skills, more self-stimulatory behavior, and some regression Modifiers: NR

Comments:

* Baseline results reported for participants who completed Phase 2 of study.

** There were no significant differences between G1 (n=24) and G2 (n=12) on the PGI.

Aman et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Aman et al., 2009 Country: US Practice setting: Academic Intervention setting: Clinic and home Enrollment period: NR Funding: NIMH; Johnson and Johnson provided risperidone Author industry relationship disclosures: 7 of 28 Abbott (1) Boehringer- Ingelheim (1) Bristol-Myers Squibb (5) CureMark (1) Eli Lilly (1) Forest (2) Janssen (2) Johnson & Johnson (2) Neuropharm (3) Novartis (1) Noven (1) Organon (1) Shire (2) Sigma Tau (1) Supernus (1) Targacept (1) Design: RCT | Intervention: Risperidone administered over first 4 weeks Dosage by weight:; - 14–20 kg: 0.25 mg/day with gradual increases to maximum of 1.75 mg; - 20–45 kg: 0.5 mg/day with gradual increases to maximum of 2.5 mg; - > 45 kg: 0.5 mg/day with gradual increases to maximum of 3.5 mg; If response to risperidone was unsatisfactory, treatment was switched to aripiprazole, which was increased as risperidone was tapered Parent training: delivered by one therapist/parent or couple; 11 core treatment sessions and 3 optional treatment sessions/booster session and two follow-up phone consults Assessments: Stanford Binet IQ, LIPS, MSEL Diagnostic assessment, medical evaluation (including electrocardiogram, medical history, routine lab tests), ADI-R inter- view, parent ratings on Home Situations Questionnaire and ABC, and IQ testing; VABS, CGI-S, CY-BOCS Assessed at 8 weeks for response to risperidone At 16 weeks, a face-to- face “booster” session and 2 follow-up phone consultations (conducted at 2 week intervals) to maintain treatment gains Groups: G1: risperidone G2: risperidone plus parent training | Inclusion criteria:; - Presence of PDD (autism, PDD-NOS, Asperger’s) established by DSM-IV-TR clinical criteria and corroborated by ADI-R; - Age 4–13 years; - Score of ≥ 18 on ABC irritability subscale; - CGI-S score ≥ 4; - Medication free 2 weeks for most psychotropic drugs and 4 weeks for fluoxetine and/or depot neuroleptics; - IQ ≥ 35 or mental age ≥ 18 months as assessed by Stanford Binet, LIPS, or Mullen Scales of Development; - If taking anticonvulsant, seizure-free ≥ 6 months and with stable dose for 4 weeks; Exclusion criteria:; - Positive HCG pregnancy test for females; - Previous adequate trial of risperidone; - Other PDD (e.g., Rett’s, childhood disintegrative disorder); - Lifetime diagnosis of schizophrenia, other psychotic disorder, or bipolar disorder; - Current diagnosis of major depression, obsessive-compulsive disorder, or substance abuse; - Significant medical condition (e.g., heart, liver, renal, pulmonary disease), unstable seizure disorder, or significant abnormality on routine laboratory tests; Age, years ± SD: G1: 7.5 ± 2.80 G2: 7.38 ± 2.21 | Social skills: ABC social withdrawal score, mean ± SD: G1: 17.1 ± 8.37 G2: 15.2 ± 9.01 VABS socialization score, mean ± SD: G1: 53.5 ± 14.4 G2: 59.5 ± 15.0 Communication/language: ABC inappropriate speech score, mean ± SD: G1: 6.37 ± 4.03 G2: 5.75 ± 3.43 VABS communication score, mean ± SD: G1: 53.2 ± 19.9 G2: 61.1 ± 20.9 Repetitive behavior: ABC stereotypic behavior score, mean ± SD: G1: 10.6 ± 5.46 G2: 7.59 ± 5.2 Problem behavior: Home Situations Questionnaire score, mean ± SD: G1: 4.16 ± 1.47 G2: 4.31 ± 1.67 ABC irritability score, mean ± SD: G1: 29.7 ± 6.10 G2: 29.3 ± 6.97 ABC hyperactivity/noncompliance score, mean ± SD: G1: 36.1 ± 6.86 G2: 35.3 ± 9.30 Adaptive behavior: VABS daily living skills score, mean ± SD: G1: 41.1 ± 19.8 G2: 50.8 ± 18.5 | Social skills: ABC social withdrawal score, week 24, mean ± SD G1: 6.44 ± 7.16 G2: 4.26 ± 5.17 G1/G2: P = 0.78 Communication/language: ABC inappropriate speech score, week 24, mean ± SD: G1: 3.30 ± 3.66 G2: 2.56 ± 2.93 G1/G2: P = 0.20 Repetitive behavior: ABC stereotypic behavior score, week 24, mean ± SD: G1: 6.25 ± 5.68 G2: 3.20 ± 4.09 G1/G2: P = 0.04 Problem behavior: Home Situations Questionnaire score, week 24, mean ± SD: G1: 1.68 ± 1.36 G2: 1.23 ± 1.36 G1/G2: P = 0.006 ABC irritability score, week 24, mean ± SD: G1: 14.53 ± 9.90 G2: 10.96 ± 6.64 G1/G2: P = 0.01 ABC hyperactivity/noncompliance score, week 24, mean ± SD: G1: 20.78 ± 12.38 G2: 15.38 ± 10.23 G1/G2: P = 0.04
| Co-interventions held stable during treatment: NR Treatment fidelity assessed: Yes Frequency of contact during study: Weekly for first 18 weeks Concomitant therapies, n (%): Anticonvulsant medication: G1: 4 (8.2) G2: 0 N at enrollment: G1: 49 G2: 75 N at 24 week follow-up: G1: 40 G2: 55 | Mental age: NR Gender, n (%): Male: 105 (85) Female: 19 (15) Race/ethnicity, n (%): White/non-Hispanic: G1: 34 (69.4) G2: 59 (78.7) Hispanic: G1: 7 (14.3) G2: 4 (5.3) African American: G1: 7 (14.3) G2: 9 (12.1) Asian American: G1: 0 G2: 3 (4.0) Native American G1: 1 (2.0) G2: 0 (0) SES: Maternal education: NR Household income: NR Diagnostic approach: In Study Diagnostic tool/method: ADI, DSM-IV Diagnostic category, n (%): Autism: G1: 32 (65.3) G2: 49 (65.3) PDD-NOS: G1: 13 (26.5) G2: 22 (29.3) Aspergers: G1: 4 (8.2) G2: 4 (5.3) Other characteristics: Educational placement, n (%): Full time, regular education: G1: 10 (20.4) G2: 18 (24.0) Full time, regular education, with aide: G1: 0 G2: 3 (4.0) | Commonly occurring comorbidities: CYBOCS score, mean ± SD: G1: 16.22 ± 2.47 G2: 14.72 ± 2.85 Home Situations Questionnaire, “yes” count, mean ± SD: G1: 18.9 ± 3.46 G2: 18.6 ± 4.65 CGI-S score, n (%): Moderate/4: G1: 14 (28.6) G2: 25 (33.3) Marked/5: G1: 19 (38.8) G2: 33 (44.0) Severe/6: G1: 15 (30.6) G2: 17 (22.7) Extreme/7: G1: 1 (2.0) G2: 0 (0) VABS composite score, mean ± SD: G1: 45.8 ± 15.5 G2: 53.1 ± 15.7 Educational/cognitive/academic attainment: IQ category, n (%): Average: G1: 11 (22.5) G2: 28 (38.4) Borderline: G1: 12 (24.5) G2: 18 (24.7) Mild intellectual disability (ID): G1: 9 (18.4) G2: 14 (19.2) Moderate ID: G1: 17 (34.7) G2: 13 (17.8) | Commonly occurring comorbidities: CYBOCS score, week 24, mean ± SD: G1: 11.86 ± 4.47 G2: 10.11 ± 3.83 G1/G2: P = 0.62 Harms, n (%): Rhinitis: G1: 39 (79.6) G2: 60 (80.0) G1/G2: P = 0.96 Cough: G1: 39 (79.6) G2: 58 (77.3) G1/G2: P = 0.77 Appetite increase: G1: 38 (77.6) G2: 55 (73.3) G1/G2: P = 0.6 Fatigue: G1: 33 (67.5) G2: 60 (80) G1/G2: P = 0.11 Weight increase: G1: 40 (81.6) G2: 53 (70.7) G1/G2: P = 0.17 Somnolence: G1: 24 (49.0) G2: 32 (42.7) G1/G2: P = 0.49 Vomiting: G1: 19 (38.8) G2: 34 (45.3) G1/G2: P = 0.47 Excessive saliva: G1: 16 (32.7) G2: 36 (48.0) G1/G2: P = 0.09 Enuresis: G1: 16 (32.7) G2: 32 (42.7) G1/G2: P = 0.26 Insomnia: G1: 24 (49.0) G2: 23 (30.7) G1/G2: P = 0.04
| | Regular education, with some special education: G1: 5 (10.2) G2: 4 (5.3) Special education classroom: G1: 8 (10.3) G2: 14 (18.7) Special elementary school: G1: 3 (6.1) G2: 2 (2.7) Home school: G1: 4 (8.2) G2: 5 (6.7) Special preschool: G1: 11 (22.4) G2: 11 (14.7) Regular preschool: G1: 6 (12.2) G2: 8 (10.7) No school: G1: 2 (4.1) G2: 12 (16.0) | | Headache: G1: 18 (36.7) G2: 25 (33.3) G1/G2: P = 0.7 Diarrhea: G1: 17 (34.7) G2: 24 (32.0) G1/G2: P = 0.76 Constipation: G1: 18 (36.7) G2: 21 (28.0) G1/G2: P = 0.31 Skin rash: G1: 12 (24.5) G2: 24 (32.0) G1/G2: P = 0.37 Anxiety: G1: 14 (28.6) G2: 22 (29.3) G1/G2: P = 0.93 Dyspepsia: G1: 9 (18.4) G2: 21 (28.0) G1/G2: P = 0.22 Polydipsia: G1: 11 (22.5 G2: 17 (22.7) G1/G2: P = 0.98 Nausea: G1: 12 (24.5) G2: 15 (20.0) G1/G2: P = 0.55 Pyrexia: G1: 8 (16.3) G2: 18 (24.0) G1/G2: P = 0.3 Dry mouth: G1: 14 (28.6) G2: 11 (14.7) G1/G2: P = 0.06 Pharyngitis: G1: 9 (18.4) G2: 14 (8.7) G1/G2: P = 0.97 Tachycardia: G1: 7 (14.3) G2: 11 (14.7) G1/G2: P = 0.95

Bass et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Bass et al., 2009 Country: US Practice setting: Academic Intervention setting: Residential center Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: RCT | Intervention: Therapeutic horseback riding sessions, 1 hour per week over the span of 12 weeks, consisting of:; - Mounting/dismounting: 5 minute instruction sessions aimed at stimulating verbal communication; - Exercises: 10 minute warm-up with stretches, side walkers practice giving verbal/modeled/physical prompts; - Riding Skills: 15 minutes riding skill practice aimed to stimulate sensory seeking, gross fine motor domains; - Mounted Games: 20 minute segment focusing on group and individual games to stimulate social and communication skills; - Horsemanship: 10 minutes of taking part in grooming activities; Assessment: SRS and Sensory Profile, pre- and post-intervention Groups: G1: therapeutic horseback riding G2: waitlist group Provider: Staff at the Good Hope Equestrian Training Center Measure of treatment fidelity reported: No Co-interventions held stable during treatment: Yes Concomitant therapies, n: None: G1: 8 G2: 3 | Inclusion criteria:; - Met criteria for DSM-IV- TR autism spectrum diagnosis; - Parents had to consent to pre-testing, 12 weeks of therapeutic horseback riding, and one post testing session; - No previous exposure to equine activities; Exclusion criteria:; - See inclusion criteria; Age, years ± SD (range): G1: 6.95 ± 1.67 (5–10) G2: 7.73 ± 1.65 (4–10) Mental age: NR Gender, n: Male: G1: 17 G2: 12 Female: G1: 2 G2: 3 Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: DSM-IV-TR Diagnostic category, n: Mild autism: G1: 6 (18) G2: 5 (15) Moderate autism: G1: 10(29) G2: 6(18) Severe autism: G1: 2 (6) G2: 3(9) Aspergers: G1: 1(3) G2: 1(3) | Social skills: SRS score, mean ± SD: Total: G1: 85.9 ± 37.5 G2: 89.3 ± 35.4 Social cognition: G1: 20.8 ± 7.3 G2: 11.5 ± 3.6 Social awareness: G1: 12.1 ± 4.7 G2: 11.5 ± 3.6 Social motivation: G1: 17.3 ± 7.1 G2: 18.2 ± 7.1 Motor skills: Sensory Profile score, mean ± SD: Fine motor/perception: G1: 8.9 ± 3.5 G2: 8.6 ± 2.9 Sedentary: G1: 13.5 ± 5 G2: 11.9 ± 5.1 Sensory: Sensory Profile score, mean ± SD: Total: G1: 237.6 ± 55.9 G2: 240.9 ± 50.9 Sensory seeking: G1: 58.4 ± 10.6 G2: 53.9 ± 10.9 Sensory sensitivity: G1: 15.7 ± 3.6 G2: 16.1 ± 4.6 Educational/cognitive/academic attainment: Sensory Profile inattention/distractibility score, mean ± SD: G1: 21 ± 7.1 G2: 21.6 ± 4.6 | Social skills: SRS score, mean ± SD: Total: G1: 73.6 ± 24.1 G2: 94.4 ± 32.1 G1/BL: P < 0.017 G2/BL: P = NS G1/G2: P < 0.05 Social cognition: G1: 16.1 ± 5.8 G2: 18.9 ± 6.6 G1/G2: P = NS Social awareness: G1: 9.9 ± 2.7 G2: 11.1 ± 3.2 G1/G2: P = NS Social motivation: G1: 12.5 ± 5.9 G2: 16.2 ± 6.7 G1/BL: P < 0.003 G2/BL: P = NS G1/G2: P < 0.05 Motor skills: Sensory Profile score, mean ± SD: Fine motor/perception: G1: 9.4 ± 3.0 G2: 8.7 ± 3.1 G1/G2: P = NS Sedentary: G1: 16 ± 3.3 G2: 11.3 ± 4.8 G1/BL: P < 0.001 G2/BL: P = NS G1/G2: P < 0.01 Sensory: Sensory Profile score, mean ± SD: Total: G1: 269.4 ± 51.6 G2: 245.7 ± 50.3 G1/BL: P < 0.001 G2/BL: P = 0.101 G1/G2: P < 0.01
Author: Bass et al., 2009 Country: US Practice setting: Academic Intervention setting: Residential center Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: RCT | Occupational therapy: G1: 6 G2: 5 Occupational/speech therapy: G1: 2 G2: 0 Occupational/speech/physical therapy: G1: 0 G2: 1 Occupational/physical therapy: G1: 2 G2: 5 Speech therapy: G1: 1 G2: 1 N at enrollment: G1: 19 G2: 15 N at follow-up: G1: 19 G2: 15 | Other characteristics, n: Verbal: G1: 9 G2: 6 Non-verbal G1: 10 G2: 9 | | Sensory seeking: G1: 62 ± 9.0 G2: 53.2 ± 10.5 G1/BL: P < 0.001 G2/BL: P = NS G1/G2: P < 0.01 Sensory sensitivity: G1: 17.2 ± 2.6 G2: 15.7 ± 4.8 G1/BL: P < 0.001 G2/BL: P = NS G1/G2: P < 0.001 Educational/cognitive/academic attainment: Sensory Profile inattention/distractibility score, mean ± SD: G1: 27 ± 4.6 G2: 21.4 ± 4.5 G1/BL: P < 0.001 G2/BL: P = NS G1/G2: P < 0.01 Harms: NR Modifiers: NR

Chan et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Chan et al., 2009 Country: China Practice setting: Academic Intervention setting: Academic Enrollment period: NR Funding: Culture Homes Ltd. Author industry relationship disclosures: NR Design: RCT | Intervention: Seven-star needle stimulation, 5–10 minute treatment sessions, 5 days a week for 6 weeks. Therapist tapped the child’s skin quickly (approximately 20 times every 5 seconds) with dermatoneural medical hammer; stimulation was performed three times each on the 2 sides of the child’s back along the spine, along the midline of the front side of the body, and on dorsal and pos-terior parts of the head Assessments: Children were assessed before and after the treatment group underwent seven-star needle stimulation (baseline and 6 weeks); Parent’s Rating Questionnaire, developed for the study, on language, social interaction and behavioral problems, as well as motor functioning; quantitative electro- encephalogram (qEEG) Groups: G1: needle stimulation G2: waitlist control Co-interventions held stable during treatment: NR Frequency of contact during study: 5 days a week for 6 weeks, assessed at baseline and 6 weeks after treatment Concomitant therapies NR N at enrollment: G1: 16 G2: 16 N at follow-up: G1: 16 G2: 16 | Inclusion criteria:; - Children with autism; Exclusion criteria:; - See inclusion criteria; Age, mean ± SD G1: 6.85 ± 1.76 G2: 6.89 ± 1.77 Mental age: TONI, IQ ± SD: G1: 84.06 ± 15.75 G2: 86.82 ± 19.91 Gender, n: Male: G1: 13 G2: 13 Female: G1: 3 G2: 3 Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral from special education centers Diagnostic tool/method: NR Diagnostic category: NR Other characteristics: NR | Overall ratings: Parent’s Rating Questionnaire score, mean ± SD: Language: G1: NR G2: NR Social interaction: G1: NR G2: NR Stereotyped behavior: G1: NR G2: NR Motor functioning: G1: NR G2: NR Overall: G1: NR G2: NR Sensory: QEEG spectral amplitude, mean ± SD: Delta: G1: 244.80 ± 86.32 (n=7) G2: 178.20 ± 38.81 (n=9) Theta: G1: 107.71 ± 31.90 (n=7) G2: 78.73 ± 16.90 (n=9) Alpha: G1: 61.86 ± 26.66 (n=7) G2: 45.62 ± 12.21 (n=9) Beta: G1: 33.71 ± 17.16 (n=7) G2: 20.20 ± 4.60 (n=9) High beta: G1: 34.23 ± 18.51 (n=7) G2: 24.19 ± 3.68 (n=9) | Overall ratings: Parent’s Rating Questionnaire score, mean change ± SD: Language: G1: 1.21 ± 0.73 G2: 0.43 ± 0.35 G1/G2: P < 0.01 Social interaction: G1: 1.07 ± 0.77 G2: 0.42 ± 0.49 G1/G2: P < 0.01 Stereotyped behavior: G1: 0.55 ± 1.08 G2: 0.34 ± 0.67 G1/G2: P = NS Motor functioning: G1: 1.03 ± 1.15 G2: 0.59 ± 0.71 G1/G2: P = NS Overall: G1: 0.97 ± 0.73 G2: 0.41 ± 0.41 G1/G2: P < 0.05 Sensory: QEEG spectral amplitude, mean ± SD: Delta: G1: 165.77 ± 81.61 (n=7) G2: 197.34 ± 51.35 (n=9) ANOVA: treatment × time (P < 0.05) G1/G2: P < 0.05 Theta: G1: 70.50 ± 15.62 (n=7) G2: 73.80 ± 12.21 (n=9) ANOVA: treatment × time (P < 0.05) G1/G2: P < 0.05
| | | | Alpha: G1: 49.89 ± 13.44 (n=7) G2: 43.36 ± 6.35 (n=9) ANOVA: treatment (P < 0.05), time × treatment (P = NS) G1/G2: P = NS Beta: G1: 26.61 ± 13.82 (n=7) G2: 28.93 ± 9.68 (n=9) ANOVA: treatment × time (P < 0.05) G1/G2: P < 0.05 High beta: G1: 18.76 ± 7.58 G2: 29.54 ± 13.47 ANOVA: treatment × time (P < 0.05) G1/G2: P < 0.05 Harms: NR Modifiers: NR

Correia et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Correia et al., 2009 Country: Portugal Practice setting: Clinic Intervention setting: Home Enrollment period: NR Funding: Fundacao para a Ciencia e a Tecnologia (FCT) Author industry relationship disclosures: NR Design: Prospective case series | Intervention: Risperidone administered with progressive increments each 2 weeks, according to weight: (i) <20 kg—beginning with 0.25mg until a maximum 1.0 mg; (ii) 20–45 kg— beginning with 0.5mg until a maximum 2.0 mg; (iii) >45 kg—beginning with 0.5mg until a maximum 3.0 mg. Dose adjusted to obtain clinical improvement and minimize motor and other side effects. Assessments: CBRF, ATEC, & BPI. Final assessment at 12 months Groups: G1: Risperidone Co-interventions held stable during treatment: NR Frequency of contact during study: at 1, 3, 6, and 12 months Concomitant therapies, n (%): received antipsychotics, no details reported N at enrollment: G1: 45 N at follow-up: G1: 31 | Inclusion criteria:; - Met the algorithm cut- off for the ADI-R and ADOS; - Developmental level or IQ> 30 and functional age > 18 months; - Free of any medication for ≥ 3 months; - Behavioral alterations of clinical significance in the health/physical/behavior subtest of the ATEC (moderate or serious problem on ≥ 2 items with no improvement after adequate educational and behavioral intervention); Exclusion criteria:; - See inclusion criteria; Age, mean years ± SD (range): 8.67 ± 4.30 (3–21) Mental age, mean/yrs (range): NR Age at diagnosis mean ± SD (range): 4.98 ± 2.99 (2–14) Gender, n (%): M: 34 (75.6) F: 11 (24.4) Race/ethnicity, n (%): Caucasian: 44 (97.8) African: 1 (2.2) SES: Maternal education: NR Household income: NR Diagnostic approach: NR Diagnostic tool/method: ADI-R and ADOS Diagnostic category: NR | Autism Treatment Evaluation Checklist (ATEC), mean ± SD.: Total: 71.36 ± 25.73 Sociability: 19.27 ± 8.22 Speech: 12.73 ± 8.02 Cognition: 15.69 ± 7.50 Behavior: 23.53 ± 8.37 Nisonger Child Behavior Rating Form (CBRF), mean ± SD: Compliant/calm: 5.56 ± 2.78 Adaptive/social: 3.00 ± 2.26 Conduct problem: 13.62 ± 6.65 Insecure/anxious: 6.58 ± 6.04 Hyperactive: 17.33 ± 5.41 Self-injury/stereotyped: 3.20 ± 3.57 Self-isolated/ritualistic: 4.13 ± 3.00 Overly sensitive: 5.31 ± 3.77 Behavior Problems Inventory (BPI), mean ± SD: Self-injurious behavior, frequency: 3.07 ± 3.85 Self-injurious behavior, intensity: 2.27 ± 2.68 Stereotypic behavior, frequency: 12.4 ± 10.16 Stereotypic behavior, intensity: 7.80 ± 6.08 Aggressive/destructive behavior, frequency: 9.07 ± 9.97 | Overall ratings: ATEC total, mean ± SD: 34.71 ± 23.63 P = 1.581×10^−10^ Social skills: ATEC sociability, mean ± SD: 9.29 ± 7.64 P=2.646×10^−11^ Communication/language: ATEC speech, mean ± SD: 8.32 ± 7.53 P = 1.373×10^−05^ Repetitive behavior: CBRF self- injury/stereotyped, mean ± SD: 0.81 ± 1.78 P = 2.364×10^−4^ CBRF self- isolated/ritualistic, mean ± SD: 1.90 ± 1.42 P = 3.336×10^−5^ BPI stereotypic behavior, frequency, mean ± SD: 6.29 ± 6.88 P = 3.515×10^−3^ BPI stereotypic behavior, intensity, mean ± SD: 3.87 ± 3.98 P = 2.149×10^−3^ Problem behavior: ATEC behavior, mean ± SD: 6.55 ± 4.50 P = 3.211×10^−15^
| | Other characteristics, n (%): Etiology: Idiopathic : 41 (91.1) Fragile X: 2 (4.4) Chromosomal abnormalities: 1 (2.2) Mitochondrial disease: 1 (2.2) Obesity: 2 (4.4) Mental retardation: Absent (IQ ≥70): 17 (37.8) Mild (IQ 50–69): 14 (31.1) Moderate (IQ 35–49): 11 (24.4) Severe (IQ<35): 3 (6.7) Epilepsy: 1 (2.2) Language status: Non-verbal: 25 (55.6) Verbal: 20 (44.4) Verbal regression: 5 (11.1) Risperidone administration pattern: Once a day: 4 (8.9) Twice a day: 36 (80.0) Three times a day: 2 (4.4) Weight: 37.89 ± 21.19 BMI: 19.29 ± 5.04 Waist Circumference: 66.61 ± 16.88 Prolactin: 13.71 ± 12.50 | Aggressive/destructive behavior, intensity: 6.58 ± 6.81 | CBRF conduct problem, mean ± SD: 3.58 ± 2.32 P = 2.529×10^−6^ CBRF hyperactive, mean ± SD: 5.13 ± 3.74 P = 2.515×10^−6^ CBRF overly sensitive, mean ± SD: 1.42 ± 1.48 P = 1.638×10^−5^ BPI self-injurious behavior, frequency, mean ± SD: 0.58 ± 1.26 P = 5.526×10^−4^ BPI self-injurious behavior, intensity, mean ± SD: 0.68 ± 1.64 P = 4.676×10^−3^ BPI aggressive/destructive behavior, frequency, mean ± SD: 1.77 ± 3.87 P = 1.412×10^−4^ BPI aggressive/destructive behavior, intensity, mean ± SD: 1.65 ± 3.42 P = 1.658×10^−4^ Adaptive behavior: CBRF compliant/calm, mean ± SD: 1.74 ± 1.24 P = 1.027×10^−5^
| | | | CBRF adaptive/social, mean ± SD: 0.61 ± 0.84 P = 1.842×10^−5^ CBRF insecure/anxious, mean ± SD: 0.97 ± 1.38 P = 2.638×10^−5^ Educational/cognitive/academic attainment: ATEC cognition, mean ± SD: 10.55 ± 7.97 P = 2.148×10^−5^ Harms: Weight, mean kg ± SD: 42.67 ± 22.66 BMI, mean kg/m^2^ ± SD: 21.11 ± 5.55 P = 1.923×10^−7^ Waist circumference, mean cm ± SD: 73.92 ± 19.01 P = 2.053×10^−9^ Prolactin, mean ng/mL ± SD: 34.50 ± 22.39 P = 3.179×10^−4^ 1 observed case of galactorrhea No extrapyramidal AEs or excessive sedation observed
| | | | Modifiers: Significant modifiers of ATEC total score changes included baseline ATEC score (P < 1×10^−16^); gender (P = 0.007); and genetic polymorphisms including HTR2A c.-1538G > A status (AA+AG vs GG; P = 0.019); HTR2C c.-995G > A status (A present vs A absent; P = 0.035); DRD3 c.25T > C (p.S9G) (TC+CC(Gly/−) vs TT (Ser/Ser); P = 0.012); and ABCB1 c.1236C > T (p.G412G) (TT+CT vs CC; P = 0.002). Significant modifiers of BMI changes included baseline BMI (P < 1×10^−16^); age (P = 7.123×10^−7^); and genetic polymorphisms including HTR2C c.68G > C (p.C23S) (G allele absent vs present; P = 0.037) and CYP2D6 (UM vs homozygous EM; P = 0.002).
| | | | Significant modifiers of Waist circumference changes included baseline Waist circumference (P < 1×10^−16^); age (P = 1.476×10^−6^); and genetic polymorphisms including HTR2C c.68G > C (p.C23S) (G allele absent vs present; P = 6.057× 10^−5)^ and CYP2D6 (PM vs. homozygous EM; P = 0.001). Significant modifiers of Prolactin changes included baseline prolactin levels (P = 0.017); Dose (P = 2.735× 10^−6)^and genetic polymorphisms including HTR2A c.-1438G > A (AA+AG vs. GG, P = 0.018); HTR2C c.68G > C (p.C23S) (G allele absent vs. present, P = 0.006) ; HTR6 c.715-2542C > T (TC+CC vs. T, P = 9.534 × 10^−5^) and BDNF c.196G > A (p.V66M) AA+AG (Met/−) vs. GG (Val/Val), P = 0.016

Cotugno, 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Cotugno, 2009 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: Prospective cohort series | Intervention: Social competency and social skills training and intervention program, 1 hour weekly group sessions for 30 weeks, employing a peer-based, group model within a stage-based cognitive-behavioral framework using group therapy, cognitive-behavioral, and skill instruction Control group: matched sample of non-ASD children not receiving treatment Assessments: WMS completed by teachers; SCDS completed by parents, six items selected from scale, two items each addressing stress/anxiety management, joint attention, and flexibility/transitions Groups: G1: social competency and social skills training and intervention program G2: non-ASD controls Ga: younger children (ages 7.0–8.2) Gb: older children (ages 10.0–11.0) Provider: Licensed group clinician Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1a: 10 G1b: 8 G2a: 5 G2b: 5 | Inclusion criteria: G1:; - Families self-referred to MGH/Youth Care; - Between the ages of 7 and 11; - Received a prior diagnosis on the autism spectrum meeting DSM-IV criteria, confirmed by neuropsychological evaluation by professionals with no connection to the program; - Obtained a Full Scale or Verbal Scale IQ on the WISC-IV within the average range (80–119) or higher; - Demonstrated no significant language or communication deficits; - Participated in at least a partial inclusion program in a regular education curriculum; G2:; ○ Randomly selected from two local public schools to match the ages and grades of the intervention groups; ○ No prior diagnosis of ASD; ○ Had never been referred to nor ever received any special education services; ○ Receiving no current psychological or school-based services (i.e. individual, group therapy, or counseling); ○ Had no prior contact with MGH/Youth Care; Exclusion criteria:; - See inclusion criteria; Age, range (years): G1a: 7.0–8.2 G1b: 10.0–11.0 G2a: 7–8 G2b: 10–11 | Overall ratings: WMS score, mean: G1a: 121.4 G1b: 120.5 G2a: 159.0 G2b: 187.0 Social Skills: WMS, teacher preferred social behavior subscale, mean: G1a: 46.2 G2b: 44.5 G2a: 59.6 G2b: 69.4 WMS, peer-preferred social behavior subscale, mean: G1a: 43.8 G1b: 44.0 G2a: 60.8 G2b: 74.0 SCDS, participants with scores of 1 or 2 on joint attention questions, n (%):^*^ G1a: 12 (60) G1b: 11 (69) Adaptive behavior: WMS, school adjustment behavior subscale, mean: G1a: 31.4 G1b: 32.0 G2a: 40.6 G2b: 43.6 SCDS, participants with scores of 1 or 2 on flexibility/transitions questions, n (%):^*^ G1a: 17 (85) G1b: 11 (69) | Overall ratings: WMS score, 9 months, mean: G1a: 138.3 G1b: 136.4 G2a: 163.6 G2b: 181.4 G1a/BL: P < 0.05 G1b/BL: P < 0.01 G2a/BL: P = NS G2b/BL: P = NS Social skills: WMS, teacher preferred social behavior sub-scale, 9 months, mean: G1a: 52.7 G1b: 48.8 G2a: 60.4 G2b: 65.2 G1a/BL: P < 0.05 G1b/BL: P < 0.05 G2a/BL: P = NS G2b/BL: P = NS WMS, peer-preferred social behavior sub-scale, 9 months, mean: G1a: 50.9 G1b: 47.0 G2a: 63.2 G2b: 72.4 G1a/BL: P < 0.05 G1b/BL: P < 0.05 G2a/BL: P = NS G2b/BL: P = NS SCDS, 9 months, participants with scores of 1 or 2 on joint attention questions, n (%):^*^ G1a: 7 (35) G1b: 4 (25)
| N at follow-up: G1a: 10 G1b: 8 G2a: 5 G2b: 5 | Mental age: G1: See inclusion criteria G2: NR Gender: NR Race/ethnicity, n (%): NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: DSM-IV Diagnostic category: NR Other characteristics: NR | Commonly occurring co-morbidities: SCDS, participants with scores of 1 or 2 on anxiety and stress management questions, n (%):^*^ G1a: 17 (85) G1b: 16 (100) | Adaptive behavior: WMS, school adjustment behavior subscale, 9 months, mean: G1a: 34.6 G1b: 41.1 G2a: 40.0 G2b: 43.8 G1a/BL: P < 0.05 G1b/BL: P < 001 G2a/BL: P = NS G2b/BL: P = NS SCDS, 9 months, participants with scores of 1 or 2 on flexibility/transitions questions, n (%):^*^ G1a: 11 (55) G1b: 5 (31) Commonly occurring co-morbidities: SCDS, 9 months, participants with scores of 1 or 2 on anxiety and stress management questions, n (%):^*^ G1a: 9 (45) G1b: 7 (44) Harms: NR Modifiers: NR

Comments:

* A score of 1 or 2 reflects no or very limited demonstrations of positive adaptive behavior.

Granpeesheh et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Granpeesheh et al., 2009 Country: US Practice setting: Specialty treatment center Intervention setting: Community Enrollment period: 1995 to 2007 Funding: NR Author industry relationship disclosures: None Design: Retrospective case series | Intervention: Early Intensive Behavioral Intervention Assessments: WISC-R and WISC-III, SB-FE, MPS, LIPS-R, MESL (AGS edition), BSID-II, DAS Groups: G1: intervention Provider: NR Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 38 N at follow-up: G1: 38 | Inclusion criteria:; - No longer presented with developmental delay in any area of functioning of which author is aware; - Placed in regular education classrooms and were earning passing grades without any special assistance; - Reason for discharge from author’s treatment was the absence of any apparent need for treatment; - Agreement of criteria must be met between a minimum of two senior clinicians who were familiar with the course and outcome of a patient’s treatment; - Patient record had to contain cognitive testing within 6 months of start of ABA services and within 6 months of stopping ABA services; Exclusion criteria:; - See inclusion criteria; Age, months ± SD (range): G1: 40.32 ± 7.27 (24–55) Mental age: NR Gender: NR Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: NR Diagnostic category, %: Autism: 100 Other characteristics: NR | Adaptive behavior: VABS composite score, mean ± SD (range): G1: 68.04 ± 7.79 (57–82) Educational/ cognitive/ academic attainment: IQ, mean ± SD (range): G1: 83.6 ± 19.15 (50–133) | Adaptive behavior: VABS composite, mean ± SD (range): G1: 88.87 ± 11.02 (69–111) Educational/ cognitive/ academic attainment: IQ, mean ± SD (range): G1: 107.9 ± 9.59 (89–128) Harms: NR Modifiers: NR

Handen, et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Handen, et al., 2009 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: PediaMed Pharmaceuticals Author industry relationship disclosures: 2 of 7 Alarus Developmental International (1) PediaMed Pharmaceuticals (1) PRA International (1) Design: RCT | Intervention: Randomized, double-blind, placebo-controlled, parallel groups, involving 12 centers in the US. Oral human immuneglobulin (IGOH; Oralgam), 140, 420, or 840 mg/day for 12 weeks (administered in divided doses of 3 capsules in the morning and 3 capsules in the evening) or placebo A computerized system used to assign and verify 1:1:1:1 randomization, with subjects balanced by site and age Assessments: MGIS (response to treatment after 12 weeks); weekly, daily status of GI signs and symptoms completed by parents Behavioral measures (ABC), CGI-I to assess the severity of behavioral symptom as completed by parents and clinicians General safety and tolerability assessed Groups: G1a: IGOH 140 mg/day G1b: IGOH 420 mg/day G1c: IGOH 840 mg/day G2: placebo Co-interventions held stable during treatment: Yes Frequency of contact during study: 2 weeks and 12 weeks Concomitant therapies: NR N at enrollment: G1a: 32 G1b: 31 G1c: 31 G2: 31 | Inclusion criteria:; - Met diagnostic criteria for autism per DSM-IV, corroborated by ADI-R; - CGI severity scale > 3 (autistic symptoms); - History of chronic, persistent GI disturbance (> 6 weeks duration); - One of following must be present: abnormal gaseousness, bloating, or symptoms of moderate-to-severe abdominal pain or discomfort; - No elective changes in concurrent therapy during the study; Exclusion criteria:; - Evidence of a GI infection based on stool laboratory tests at baseline; - Known diagnosis of other GI pathology; - Current use of antibiotics or antifungal medications, chelation therapy, medication affecting GI transit (stool softeners and bulking agents were permitted if constant doses were used for ≥ 30 days prior to screening visit and no changes in dosing was planned during the course of the study); - Changes in diet intervention within 30 days prior to the screening visit; - Changes in alternative medical therapies; - DSM-IV diagnosis of a pervasive developmental disorder other than autism; - Evidence of a seizure disorder, Fragile X syndrome, Tuberous Sclerosis Complex, liver or pancreatic disease, cystic fibrosis, or chronic infection | | Overall ratings: CGI, physician rated, n (%):Very much or much improved: G1a: 3/29 (10.3) G1b: 9/26 (34.6) G1c: 5/28 (17.9) G2: 11/28 (39.3) Minimally improved or unchanged: G1a: 25/29 (86.2) G1b: 14/26 (53.9) G1c: 21/28 (75.0) G2: 15/28 (53.6) Minimally, much or very much worse: G1a: 1/29 (3.4) G1b: 3/26 (11.5) G1c: 2/28 (7.1) G2: 2/28 (7.1) G1a/G1b/G1c/ G2: P = 0.5 CGI, parent rated, n (%): Very much or much improved G1a: 6/29 (20.7) G1b: 12/26 (46.2) G1c: 7/28 (25.0) G2: 16/29 (55.2) Minimally improved or unchanged: G1a: 21/29 (72.4) G1b: 12/26 (46.2) G1c: 17/28 (60.7) G2: 12/29 (41.4) Minimally, much, or very much worse: G1a: 2/29 (6.9) G1b: 2/26 (7.6) G1c: 4/28 (14.3) G2: 1/29 (3.4) G1a/G1b/G1c/ G2: P = 0.047
| N at follow-up: G1a: 27 G1b: 23 G1c: 24 G2: 26 | - Previous GI surgery with the exception of fundoplication, appendectomy, gastrostomy, endoscopy, pyloromyotomy, or herniorraphy; - Pregnancy; - Participation in another investigational study within 60 days prior to screening visit; - IgA deficiency (serum IgA < 5 mg/dl); - A history of severe hypersensitivity to human immunoglobulin; - Treatment with any human immunoglobulin and/or immunoglobulin products within 90 days prior to screening visit; - Concurrent medication that would compromise tolerance of drug or compliance with the protocol; Additional exclusion criteria during screening:; - Clinically significant abnormal laboratory test values; - Failure of parent or guardian to record at least 11/14 days of daily diary assessments or the weekly assessments; - GI Symptoms Score of < 5 for week 1 or 2 of the screening period; - MGIS score moderately or substantially improved during week 1 or 2 of the screening period; - Parent or guardian’s inability or unwillingness to follow directions or inability to understand how to use the electronic diary data entry system; Age, years ± SD (range): G1a: 7.4 ± 3.1 (3–13) G1b: 8.0 ± 4.1 (2–17) G1c: 7.6 ± 3.5 (3–13) G2: 6.2 ± 3.3 (2–14) | | Responders to treatment, MGIS, ITT population, n: G1a: 11/32 G1b: 9/31 G1c: 11/31 G2: 14/31 G1/G2: P = 0.22 Dose-response trend: P = 0.52 Responders to treatment, MGIS, CE population, n: G1a: 9/20 G1b: 6/20 G1c: 8/20 G2: 10/22 G1/G2: P = NR (“similar to ITT population”) Dose-response trend: P = 0.59 Medical: Responders to treatment by predominant bowel pattern, n: Diarrhea: G1a: 3/11 G1b: 2/9 G1c: 6/15 G2: 5/14 Dose-response trend: P = 0.69 Constipation: G1a: 7/20 G1b: 7/20 G1c: 3/11 G2: 7/12 Dose-response trend: P = 0.22 Alternating: G1a: 1/1 G1b: 0/2 G1c: 2/5 G2: 2/5 Dose-response trend: P = 0.79
| | Age, n (%): 2–11 years: G1a: 28 (87.5) G1b: 27 (87.1) G1c: 27 (87.1) G2: 27 (87.1) 12–17 years: G1a: 4 (12.5) G1b: 4 (12.9) G1c: 4 (12.9) G2: 4 (12.9) Mental age: NR Gender, n (%): Male: G1a: 28 (87.5) G1b: 28 (90.3) G1c: 26 (83.9) G2: 25 (80.6) Female: G1a: 4 (12.5) G1b: 3 (9.7) G1c: 5 (16.1) G2: 6 (19.4) Race/ethnicity, n (%): Caucasian: G1a: 28 (87.5) G1b: 27 (87.1) G1c: 27 (87.1) G2: 23 (74.2) African-American: G1a: 1 (3.1) G1b: 0(0) G1c: 0(0) G2: 2 (6.5) Asian: G1a: 0(0) G1b: 1 (3.1) G1c: 0(0) G2: 0(0) Hispanic: G1a: 2 (6.3) G1b: 2 (6.5) G1c: 1 (3.2) G2: 4 (12.9) Other: G1a: 0 (0) G1b: 2 (6.5) G1c: 3 (9.7) G2: 2 (6.5) SES: Maternal education: NR Household income: NR | | Responders to treatment with regression-onset of autistic symptoms, n G1a: 6/18 G1b: 7/20 G1c: 9/21 G2: 9/21 Dose-response trend: P = 0.85 Responders to treatment by age, n: 2–11 years: G1a: 9/28 G1b: 7/27 G1c: 9/27 G2: 13/27 Dose-response trend: P = 0.36 12–17 years: G1a: 2/4 G1b: 2/4 G1c: 2/4 G2: 1/4 Dose-response trend: P = 0.58 Harms, n (%): One or more AEs, %: G1a: 77.4 G1b: 74.2 G1c: 74.2 G2: 80.6 Discontinued due to AEs, n: G1a: 2 G1b: 2 G1c: 3 G2: 1 Infections and infestations:^**^ G1a: 14 (45.2) G1b: 17 (54.8) G1c: 15 (48.4) G2: 16 (51.6) Gastrointestinal disorders:^**^ G1a: 12 (38.7) G1b: 14 (45.2) G1c: 10 (32.3) G2: 9 (29.0)
| | Diagnostic approach: In Study/Referral Referral – experienced physicians In Study – using scale Diagnostic tool/method: DSM-IV, ADI-R Diagnostic category, n (%): Autism: 125 Other characteristics, n (%): Predominant bowel pattern: Diarrhea: G1a: 11 (34.4) G1b: 9 (29.0) G1c: 15 (48.4) G2: 14 (45.2) Constipation: G1a: 12 (38.7) G1b: 20 (62.5) G1c: 20 (64.5) G2: 11 (35.5) Alternating: G1a: 1 (3.1) G1b: 2 (6.5) G1c: 5 (16.1) G2: 5 (16.1) | | Psychiatric disorders:^**^ G1a: 6 (19.4) G1b: 5 (16.1) G1c: 6 (19.4) G2: 6 (19.4) Respiratory, thoracic, and mediastinal disorders:^**^ G1a: 8 (25.8) G1b: 5 (16.1) G1c: 2 (6.5) G2: 4 (12.9) Skin and subcutaneous tissue disorders:^**^ G1a: 8 (25.8) G1b: 2 (6.5) G1c: 2 (6.5) G2: 3 (9.7) General disorders and administration site conditions:^**^ G1a: 3 (9.7) G1b: 5 (16.1) G1c: 1 (3.2) G2: 2 (6.5) Nervous system disorders:^**^ G1a: 2 (6.5) G1b: 2 (6.5) G1c: 3 (9.7) G2: 0 Injury, poisoning, and procedural complications:^**^ G1a: 2 (6.5) G1b: 0 G1c: 3 (9.7) G2: 1 (3.2) Investigations:^**^ G1a: 1 (3.2) G1b: 0 G1c: 2 (6.5) G2: 1 (3.2) Metabolism and nutrition disorders:^**^ G1a: 1 (3.2) G1b: 1 (3.2) G1c: 1 (3.2) G2: 1 (3.2)
| | | | Eye disorders:^**^ G1a: 1 (3.2) G1b: 2 (6.5) G1c: 0 G2: 0 Blood and lymphatic system disorders:^**^ G1a: 1 (3.2) G1b: 0 G1c: 0 G2: 1 (3.2) Renal and urinary disorders:^**^ G1a: 0 G1b: 0 G1c: 0 G2: 2 (6.5) Ear and labyrinth disorders:^**^ G1a: 1 (3.2) G1b: 0 G1c: 0 G2: 0 Immune system disorders:^**^ G1a: 1 (3.2) G1b: 0 G1c: 0 G2: 0 Vascular disorders:^**^ G1a: 0 G1b: 0 G1c: 1 (3.2) G2: 0 Modifiers: NR

Comments:

* Each subject was considered a responder if he or she was moderately improved or substantially improved on at least 2 of the last 4 assessments or somewhat improved for all of the last 4 assessments of the MGIS.

** There were no significant differences in adverse events between treatment groups.

Hayward et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Hayward et al., 2009 Eikeseth et al., 2009† Country: UK Practice setting: Academic Intervention setting: Home and clinic Enrollment period: Autumn 1998 to Spring 2005 Funding: NIH Author industry relationship disclosures: 3 of 5† NOVA Institute for Children with Developmental Disorders (1) UK YAP (3) Design: Prospective cohort study Retrospective case series (subgroup analysis)† | Intervention: UCLA intensive ABA, either clinic based (G1) or parent managed (G2) Duration: 1 year Frequency, hours/week, mean ± SD: G1: 37.4 ± 3.47 G2: 34.2 ± 5.29 G1/G2: P = NS Supervision intensity per month, hours (range):† G2: 5.2 (2.9–7.8) Cumulative supervision intensity, hours ± SD (range):† G2: 73.05 ± 24.80 (40–109.5) Assessments: ADI-R, administered by first author BSID-R or WPPSI-R (depending on chronological age), Merrill-Palmer Scale of Mental Tests, RDLS, and VABS conducted by an independent psychologist Groups: G1: clinic based ABA G2: parent managed ABA Provider: Clinic-based:; - Tutors: received basic and advanced theory seminars, a 60-hour practicum, continued training and supervision from senior tutor and program consultant; - Senior tutor: ≥ 1 year experience working as a tutor with > 3 children; - Program consultant: ≥ 3 years clinical experience as both tutor and senior tutor | Inclusion criteria:; - Joined UK Young Autism Project within the enrollment period; - Diagnosis of autism according to ICD-10 criteria; - Age at intake between 24–42 months; - No other severe medical conditions certified by medical practitioner; Exclusion criteria:; - See inclusion criteria; Age, months ± SD: G1: 35.7 ± 6.2 G2: 34.4 ± 5.7 Mental age: See baseline measures Gender, n: Male: G1: 19 G2: 15 Female: G1: 4 G2: 6 Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral, confirmed in study Diagnostic tool/method: Confirmed by ADI-R Diagnostic category: NR Other characteristics: NR | Communication/language: RDLS score, mean ± SD: Comprehension: G1: 20.0 ± 0.0 G2: 20.7 ± 2.8 G1/G2: P = NS Expressive: G1: 20.2 ± 1.0 G2: 20.7 ± 3.3 G1/G2: P = NS Adaptive behavior: VABS composite score, mean ± SD: G1: 62.3 ± 6.8 G2: 65.1 ± 10.4 G1/G2: P = NS Educational/cognitive/academic attainment: IQ, mean ± SD: G1: 53.5 ± 15.1 G2: 54.1 ± 15.1 G1/G2: P = NS Visual-spatial IQ, mean ± SD: G1: 74.8 ± 22.6 G2: 76.2 ± 18.2 G1/G2: P = NS | Communication/language: RDLS score, mean ± SD: Comprehension: G1: 26.7 ± 7.0 G2: 28.4 ± 9.5 G1/G2: P = NS G1+G2/BL: P < 0.01 Expressive: G1: 26.4 ± 6.1 G2: 27.6 ± 7.6 G1/G2: P = NS G1+G2/BL: P < 0.01 Adaptive behavior: VABS composite score, mean ± SD: G1: 68.4 ± 14.5 G2: 72.5 ± 17.3 G1/G2: P = NS G1+G2/BL: P < 0.001 Educational/ cognitive/ academic attainment: IQ, mean ± SD: G1: 70.9 ± 19.6 G2: 68.9 ± 22.1 G1/G2: P = NS G1+G2/BL: P < 0.001 Visual-spatial IQ, mean ± SD: G1: 89.4 ± 29.2 G2: 82.1 ± 28.0 G1/G2: P = NS G1+G2/BL: P < 0.001 Harms: NR
| Parent-based:; - Parents were supervised for > 6 hours every 6 weeks by program consultant from clinic-based program; Measure of treatment fidelity reported: Yes Co-interventions held stable during treatment: Yes Concomitant therapies: NR N at enrollment: G1: 23 G2: 21 N at follow-up: G1: 23 G2: 21 G2: 19† | | | Modifiers: Visual-spatial IQ at intake was significantly correlated with change in VABS composite score at 1 year (r = 0.64; P < 0.01) and change in IQ at 1 year (r = 0.38; P < 0.05) In G2, intensity of supervision was significantly correlated with change in IQ at 14 month follow-up (r = 0.45; P < 0.05); estimated linear regression line has slope of 0.210 (P < 0.05)† In G2, visual-spatial IQ at intake was significantly correlated with change in IQ at 14 month follow-up (r = 0.63; P < 0.01)†

Itzchak et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Itzchak et al., 2009 Country: Israel Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: Prospective cohort Note: See related studies: Ben Itzchak et al. 2007{#252}, Zachor et al. 2007{#5652}, Ben Itzchak et al. 2007{#538); overlap among these not clear | Intervention: Participants received either behavioral (n=40) or eclectic (n=28) treatment. Behavioral was 1-to-1 individualized treatment for 35 hrs/week addressing various skills such as imitation, receptive and expressive language, joint attention, non-verbal communication, preacademic skills, play, fine motor skills and adaptive living skills Eclectic was small-group activities supervised by special education teacher, individual therapy with various therapists (i.e., speech and language, occupational and music therapies, and structured cognitive teaching; each provided 2 hr of individual, 1 hr of group therapy, and 1 hr of consultation to the team), and included parent training to address problem behaviors Groups: G1: Unchanged diagnosis at 1 year G2: Improved autism diagnosis to ASD or off spectrum at 1 year Provider: Special education teacher, speech and language therapists, occupational therapists, music therapists, behavior analysts Assessment: ADI-R, ADOS, MSEL, VABS, changes in the severity of stereotyped behaviors. Measure of treatment fidelity reported: No | Inclusion criteria:; - Meeting criteria for autism disorder on each of the measures (DSMIV, ADI-R, ADOS); Exclusion criteria:; - See inclusion criteria; Age, months ± SD: G1: 25.1 ± 3.8 G2: 26.3 ± 4.6 Mental age: NR Gender, n (%): Male: G1: 49 (92) G2: 13 (87) Female: G1: 4 (8) G2: 2 (13) Race/ethnicity: NR SES: Parental education, years ± SD: G1: 14.8 ± 2.8 G2: 3.7 ± 3.5 Maternal education, years ± SD: G1: 14.5 ± 2.5 G2: 14.9 ± 2.5 Household income: NR Diagnostic approach: In Study Diagnostic tool/method: Clinical evaluation by a neuro-developmental pediatrician; ADOS, ADI Diagnostic category, n (%): Autism: 68 (100) Other characteristics: Parental age, years ± SD: G1: 36.2 ± 6.5 G2: 36.4 ± 5.9 Maternal age, years ± SD: G1: 32.5 ± 5.4 G2: 33.7 ± 5 | Overall measures: ADOS algorithm, mean ± SD: G1: 18.3 ± 2.6 G2: 15.9 ± 2.7 Communication/language: MSEL receptive language score, mean ± SD: G1: 28.1 ± 13.9 G2: 37.4 ± 14.1 MSEL expressive language score, mean ± SD: G1: 27.4 ± 10.4 G2: 32.9 ± 14.6 Social Skills: VABS socialization score, mean ± SD: G1: 69.2 ± 7.9 G2: 68.6 ± 8.3 Educational/cognitive/academic attainment: MSEL visual score, mean ± SD: G1: 38.2 ± 12 G2: 40.8 ± 11.2 Motor skills: MSEL fine motor score, mean ± SD: G1: 31.7 ± 14 G2: 36.7 ± 12.5 VABS motor skills score, mean ± SD: G1: 86.2 ± 11.9 G2: 88.5 ± 9.9 Adaptive behavior: VABS communication score, mean ± SD: G1: 67.8 ± 10.1 G2: 67.6 ± 6.4 VABS daily living score, mean ± SD: G1: 68.3 ± 6.9 G2: 69.3 ± 5.9 | Overall measures: ADOS algorithm, 1 year, mean ± SD: G1: 16.6 ± 3.2 G2: 9.3 ± 2 Communication/language: MSEL receptive language score, 1 year, mean ± SD: G1: 34 ± 13 G2: 45.7 ± 10.5 G1/BL: P < 0.001 G2/BL: P < 0.01 MSEL expressive language score, 1 year, mean ± SD: G1: 32.2 ± 13.8 G2: 43.8 ± 13.3 G1/BL: P < 0.01 G2/BL: P < 0.01 Social Skills: VABS socializetion score, 1 year, mean ± SD: G1: 70.1 ± 14.2 G2: 77 ± 10.5 G1/BL: P = NS G2/BL: P < 0.05 Educational/cognitive/academic attainment: MSEL visual score, 1 year, mean ± SD: G1: 35.5 ± 14.6 G2: 50 ± 7.41 G1/BL: P = NS G2/BL: P < 0.05 Motor skills: MSEL fine motor score, 1 year, mean ± SD: G1: 30 ± 13 G2: 35.9 ± 15.9 G1/BL: P = NS G2/BL: P = NS
| Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 53 G2: 15 N at follow-up: G1: 53 G2: 15 | | | VABS motor skills score, 1 year, mean ± SD: G1: 75.6 ± 13.1 G2: 80.9 ± 16.3 G1/BL: P < 0.001 G2/BL: P = NS Adaptive behavior: VABS communication score, 1 year, mean ± SD: G1: 72.3 ± 16.1 G2: 82.2 ± 12.9 G1/BL: P < 0.05 G2/BL: P < 0.001 VABS daily living score, 1 year, mean ± SD: G1: 69.2 ± 7.9 G2: 75.4 ± 13.3 G1/BL: P = NS G2/BL: P = NS Harms: NR Modifiers: There was a significant (time × group) interaction in the ADOS stereotyped behaviors score (P < 0.05); a significant decrease in stereotyped behavior and restricted interests was noted for G1 (P < 0.000) but not for G2.

Jahromi et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Posey et al., 2007* Jahromi et al., 2009^ RUPP, 2005† Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: November 2001 to September 2003 Funding: NIH, Korczak Foundation Author industry relationship disclosures: NR† 8 of 18* Abbott (1) Amgen (1) Bard CR (1) Bristol-Myers Squibb (4) Cephalon (1) Forest (3) GSK (1) Jannssen (4) Johnson and Johnson (2) Lilly (5) McNeil (1) Merck (1) Novartis (2) Pediamed (2) Pfizer (3) Shire (2) UCB (1) Wyeth (2) 7 of 15^ Bristol-Myers Squibb (6) Forest (3) Jannssen (4) Lilly (4) McNeil (3) Neuropharm (3) Novartis (2) Organon (1) Pfizer (1) Shire (3) Supernus (2) UCB (1) Wyeth (1) Design: Randomized crossover trial with open label extension phase | Intervention, test dose phase: Day 1: placebo pill; then 2 days each of 3 different doses of methylphenidate (0.125, 0.250, 0.500 mg/kg per dose) 3 times daily (3^rd^ dose daily at half of the earlier doses), in a stepwise fashion; if participants had intolerable side effects to methylphenidate, they did not continue to trial phase Intervention, randomized crossover phase: Subjects tolerating methylphenidate during the test-dose phase received a week of placebo and one week each of 3 different dose levels (low, medium, high) of methylphenidate, administered by subject weight. Participants who could not tolerate the high dose of methylphenidate received two weeks of the medium dose (n=16; leading to 77 trials of medium dose in 62 subjects); the high dose did not follow the placebo phase to avoid abrupt exposure to the drug. The 4 pm dose could be dropped by the prescribing clinician to reduce insomnia if it occurred. 3 daily doses administered at 8 am, 12 pm, and 4 pm, respectively; dosage (mg) by weight: 16 to < 24 kg (n=29): Low: 2.5, 2.5, 2.5 Medium: 5.0, 5.0, 2.5 High: 10.0, 10.0, 5.0 24–34 kg (n=20): Low: 5.0, 5.0, 2.5 Medium: 10.0, 10.0, 5.0 High: 15.0, 15.0, 10.0 | Inclusion criteria:; - Children aged 5–14 years with a diagnosis of autistic disorder, Asperger disorder, or PDD-NOS based on DSM-IV criteria; - Interfering symptoms of hyperactivity and/or impulsiveness that were present for at least 6 months and began prior to the age of 7 years; - Severity confirmed by CGI severity subscale score of ≥ 4 and a total score ≥ 27 on both parent- and teacher-rated Swanson, Nolan and Pelham version IV ADHD scale, with a score of at least 10 on the hyperactivity/ impulsivity subscale; children also eligible if hyperactivity/impulsivity subscale was ≥ 15 even in the absence of notable inattentiveness; - No concurrent psychotropic medications for at least 1–3 weeks (1 week for stimulants and clonidine hydrochloride; 2 weeks for anti-depressants except fluoxetine and citalopram hydrobromide; 3 weeks for fluoxetine, citalopram hydrobromide, or antipsychotics); - Mental age of ≥ 18 months as determined by intelligence testing; - No other neuropsychiatric disorders that might require alternative medical management; - For those with a tic disorder, severity had to be mild or less on a CGI-severity subscale rating pertaining to tics only | Overall ratings: CGI severity sub-scale rating, n (%): Moderately ill: 20 (30.3) Markedly ill: 35 (52.0) Severely ill: 11 (16.7) Educational/cognitive/academic attainment: Slosson IQ, mean ± SD (range): 62.6 ± 32.9 (16–135) Social skills: VBS score, mean ± SD (range):† Socialization: 61.7 ± 16.7 (20–109) Communication/ language: VABS Communication: 62.8 ± 21.8 (20–126) Adaptive behavior: VABS composite: 56.2 ± 21.0 (20–109) VABS Daily living skills: 54.4 ± 19.8 (20–110) Problem behavior: ABC score, parent-rated, mean ± SD (range):† Irritability: 16.9 ± 10.1 (0–41) Lethargy/social withdrawal: 12.1 ± 8.9 (0–33) Stereotypy: 7.6 ± 5.9 (0–21) Hyperactivity: 33.2 ± 8.7 (2–47) Inappropriate speech: 6.0 ± 4.1 (0–12) ABC score, teacher-rated, mean ± SD (range):† Irritability: 16.1 ± 9.4 (0–43) | Overall ratings: Responded to treatment, subjects completing cross-over phase, n (%): Total: 44 (76) Optimal/best treatment:† Placebo: 9 (20) Low: 11 (25) Medium: 14 (32) High: 10 (23) Response rate, by dose, n (%):† G1: 20/61 (33) G2: 27/77 (35) G3: 18/47 (38) G5: 12/61 (20) G1/G5: P = 0.18 G2/G5: P = 0.05 (including first medium dose) G2/G5: P = 0.06 (including first and second medium dose when applicable) G3/G5: P = 0.07 Social skills:^ Joint attention (n=33), mean ± SD Initiations: G1: 23.29 ± 16.62 G2: 20.85 ± 13.01 G3: 19.27 ± 14.23 G4: 25.09 ± 15.55 G5: 18.59 ± 12.03 G1/G5: P < 0.05 G2/G5: P = NS G3/G5: P = NS G4/G5: P < 0.05 Responses: G1: 2.48 ± 1.45 G2: 1.69 ± 1.42 G3: 1.93 ± 1.48 G4: 2.24 ± 1.69 G5: 1.90 ± 1.71 G1/G5: P < 0.01 G2/G5: P = NS G3/G5: P = NS G4/G5: P = NS
| > 34 kg (n=17): Low: 5.0, 5.0, 2.5 Medium: 10.0, 10.0, 5.0 High: 20.0, 20.0, 10.0 Intervention, open label extension phase: Participants meeting the criteria for positive response during ≥ 1 week in the crossover phase underwent best-dose determination with respect to the ABC hyperactivity subscale. If positive response during 1 week only, that dose was labeled best dose; if subject responded during more than 1 week of treatment, the prescribing and rating clinicians ranked the weeks of response in order from best to worst, then the prescribing physician broke the blind for this best dose. If this best/ optimal dose was methylphenidate, the participant entered the continuation phase. Participants with no response at any week and those responding best to placebo exited the study. Assessments: CGI rated by clinician at each weekly visit; CYBOCS-PDD rated by clinician weekly; JAMES administered weekly by experimenter; ABC-C rated by teacher; SNAP-IV rated weekly by parent and teacher Groups: G1: Low dose of methylphenidate G2: Medium dose of methylphenidate G3: High dose of methylphenidate G4: Best dose of methylphenidate G5: Placebo | - No significant medical conditions (e.g., heart or liver disease) that could make treatment with methylphenidate unsafe; - For those with seizure disorder, no seizures in the past 6 months and stable anticonvulsant dose for ≥ 1 month; - No hypertension; - No treatment with an adequate trial of methylphenidate hydrochloride (0.4 mg/kg per dose given at least twice daily for ≥ 2 weeks) within the past 2 years; - No history of severe adverse response to methylphenidate; Exclusion criteria:; - See inclusion criteria; Age, yrs ± SD (range): 7.5 ± 2.2 (5.0–13.7) Mental age, children completing social observation and regulation substudy, months ± SD (range): 43.91 ± 19.72 (20–84) Gender, n (%): Male: 59 (89.4) Female: 7 (10.6) Race/ethnicity, n (%): White: 48 (72.7) African American: 9 (13.6) Asian: 6 (9.1) Hispanic or Latino: 3 (4.6) SES: Maternal education, n (%): High school graduate/GED or less: 8 (12.1) Some college or post-high school: 25 (37.9) College/advanced graduate or professional degree: 33 (50.0) Household income: NR Employed mother, n (%):44 (66.7) | Lethargy/social withdrawal: 15.5 ± 10.9 (0–42) Stereotypy: 7.6 ± 5.1 (0–19) Hyperactivity: 30.9 ± 7.9 (16–45) Inappropriate speech: 5.8 ± 3.6 (0–12) SNAP-IV, parent-rated, mean ± SD:* ADHD: 39.82 ± 8.09 Inattention: 20.21 ± 5.17 Hyperactivity/ impulsivity: 19.61 ± 4.22 Oppositional defiant disorder: 9.61 ± 6.19 SNAP-IV, teacher-rated, mean ± SD:* ADHD: 37.23 ± 7.04 Inattention: 19.30 ± 4.32 Hyperactivity/ impulsivity: 17.93 ± 4.81 Oppositional defiant disorder: 8.83 ± 5.19 CYBOCS-PDD, clinician-rated, mean ± SD:* 13.30 ± 3.74 VABS Maladaptive behaviors total: 29.2 ± 9.2 (13–51) Motor skills: Motor skills: 69.2 ± 17.8 (44–113) | Requesting: G1: 4.04 ± 2.25 G2: 3.81 ± 2.65 G3: 3.69 ± 3.27 G4: 4.13 ± 2.58 G5: 3.67 ± 2.40 G1/G5: P = NS G2/G5: P = NS G3/G5: P = NS G4/G5: P = NS Competing demands task (n=33), mean ± SD: Self-regulating behavior: G1: 19.77 ± 10.89 G2: 16.21 ± 9.03 G3: 15.80 ± 12.65 G4: 16.47 ± 13.91 G5: 12.47 ± 11.29 G1/G5: P = 0.09 G2/G5: P < 0.01 G3/G5: P = NS G4/G5: P = 0.09 Regulated affective state: G1: 12.91 ± 4.98 G2: 12.96 ± 3.85 G3: 11.67 ± 5.53 G4: 12.47 ± 4.99 G5: 9.57 ± 6.72 G1/G5: P = NS G2/G5: P < 0.05 G3/G5: P < 0.05 G4/G5: P = 0.09 Clean-up task (n=33), mean ± SD: Compliance behaviors: G1: 3.67 ± 4.87 G2: 3.67 ± 5.64 G3: 4.06 ± 4.55 G4: 3.94 ± 4.88 G5: 3.47 ± 5.41 G1/G5: P = NS G2/G5: P = NS G3/G5: P = NS G4/G5: P = NS
| Co-interventions held stable during treatment: NR Frequency of contact during study: Nightly phone contact during test dose phase; weekly clinic visits during crossover trial; visits at 4 and 8 weeks during continuation phase Concomitant therapies: NR N enrolled, test dose phase: Total: 72 N randomized, double-blind crossover phase: Total: 66 G1: 66 G2: 66 G3: 50 G4: NA G5: 66 N completing double-blind crossover phase: Total: 58 N continuing to open label extension phase (responders to methylphenidate): 35 N completing extension phase: 32 SNAP-IV, parent-rated, n:* G1: 62 G2: 63 G3: 47 G4: 64 G5: 61 SNAP-IV, teacher-rated, n:* G1: 46 G2: 48 G3: 33 G4: 55 G5: 46 | Employed father, n (%): 59 (89.4) Married, n (%): 53 (80.3) Diagnostic approach: In Study Diagnostic tool/method: ADI-R administered to corroborate the DSM-IV diagnosis of autistic disorder based on a clinical interview and examination; since ADI-R does not have specific criteria for Asperger disorder and PDD-NOS, these diagnoses followed DSM-IV Diagnostic category, n (%): Autism: 47 (71.2) PDD-NOS: 14 (21.2) Aspergers: 5 (7.6) Other characteristics: Prior medications, n (%): Stimulant: 6 (9.1) Alpha-2 adrenergic agonist: 5 (7.6) Antipsychotic: 3 (4.6) SSRI: 3 (4.6) Other: 4 (6.1) | | Regulated affective state: G1: 8.10 ± 5.18 G2: 6.88 ± 4.86 G3: 6.65 ± 6.03 G4: 7.42 ± 5.05 G5: 7.33 ± 4.86 G1/G5: P = NS G2/G5: P = NS G3/G5: P = NS G4/G5: P = NS Repetitive behavior:† See notes Problem behavior: ABC-hyperactivity subscale score, mean ± SD:† Parent-rated: G1: 23.0 ± 11.29 G2: 20.6 ± 10.27 G3: 22.1 ± 9.67 G4: 17.2 ± 9.87 G5: 26.0 ± 9.90 G1/G5: P = 0.03 (es = 0.29) G2/G5: P < 0.001 (es = 0.54) G3/G5: P = 0.003 (es = 0.40) G4/G5: P < 0.001 (es = 0.89) Teacher-rated: G1: 22.9 ± 12.84 G2: 23.6 ± 12.53 G3: 20.3 ± 11.94 G4: 20.1 ± 12.40 G5: 26.0 ± 11.66 G1/G5: P = 0.03 (es = 0.25) G2/G5: P = 0.008 (es = 0.20) G3/G5: P = 0.002 (es = 0.48) G4/G5: P < 0.001 (es = 0.48)
| Clinician CYBOCS-PDD score, n:* G1: 61 G2: 62 G3: 47 G4: 63 G5: 61 | | | SNAP-IV inattention, mean ± SD:* Parent-rated: G1: 14.58 ± 6.56 G2: 13.38 ± 6.48 G3: 14.30 ± 6.35 G4: 11.83 ± 6.02 G5: 15.59 ± 6.51 G1/G5: P = 0.15 (es = 0.15) G2/G5: P < 0.001 (es = 0.34) G3/G5: P = 0.06 (es = 0.20) G4/G5: P < 0.001 (es = 0.60) Teacher-rated: G1: 15.24 ± 6.34 G2: 14.27 ± 6.93 G3: 14.67 ± 6.88 G4: 13.98 ± 6.46 G5: 16.15 ± 6.10 G1/G5: P = 0.21 (es = 0.15) G2/G5: P < 0.001 (es = 0.29) G3/G5: P = 0.02 (es = 0.23) G4/G5: P = 0.003 (es = 0.35) SNAP-IV hyperactivity/ impulsivity, mean ± SD:* Parent-rated: G1: 13.39 ± 5.87 G2: 12.19 ± 6.06 G3: 13.49 ± 6.41 G4: 10.80 ± 5.99 G5: 15.33 ± 5.81 G1/G5: P = 0.02 (es = 0.33) G2/G5: P < 0.001 (es = 0.53) G3/G5: P = 0.01 (es = 0.30) G4/G5: P < 0.001 (es = 0.77)
| | | | Teacher-rated: G1: 12.76 ± 6.84 G2: 13.00 ± 6.71 G3: 11.45 ± 7.01 G4: 11.26 ± 6.26 G5: 14.41 ± 6.095 G1/G5: P = 0.08 (es = 0.24) G2/G5: P = 0.01 (es = 0.21) G3/G5: P = 0.005 (es = 0.42) G4/G5: P = 0.005 (es = 0.48) SNAP-IV oppositional defiant disorder, mean ± SD:* Parent-rated: G1: 6.77 ± 5.62 G2: 7.02 ± 5.90 G3: 7.53 ± 5.90 G4: 5.86 ± 4.70 G5: 7.69 ± 5.80 G1/G5: P = 0.14 (es = 0.16) G2/G5: P = 0.25 (es = 0.12) G3/G5: P = 0.66 (es = 0.03) G4/G5: P < 0.001 (es = 0.35) Teacher-rated: G1: 5.89 ± 5.43 G2: 6.65 ± 5.10 G3: 6.75 ± 5.63 G4: 5.61 ± 4.85 G5: 7.02 ± 5.80 G1/G5: P = 0.11 (es = 0.20) G2/G5: P = 0.17 (es = 0.07) G3/G5: P = 0.35 (es = 0.05) G4/G5: P = 0.04 (es = 0.26)
| | | | CYBOCS-PDD, clinician-rated, mean ± SD:* G1: 12.82 ± 4.15 G2: 12.31 ± 4.27 G3: 13.02 ± 4.11 G4: 12.13 ± 4.22 G5: 13.05 ± 3.46 G1/G5: P = 0.90 (es = 0.06) G2/G5: P = 0.21 (es = 0.19) G3/G5: P = 0.80 (es = 0.01) G4/G5: P = 0.08 (es = 0.24) Commonly occurring co-morbidities: SNAP-IV ADHD, mean ± SD:* Parent-rated: G1: 27.97 ± 11.62 G2: 25.57 ± 11.66 G3: 27.79 ± 11.63 G4: 22.63 ± 11.19 G5: 30.92 ± 11.55 G1/G5: P = 0.04 (es = 0.25) G2/G5: P < 0.001 (es = 0.46) G3/G5: P = 0.02 (es = 0.27) G4/G5: P < 0.001 (es = 0.73) Teacher-rated: G1: 28.00 ± 12.12 G2: 27.27 ± 12.21 G3: 26.12 ± 12.64 G4: 25.24 ± 11.53 G5: 30.57 ± 11.84 G1/G5: P = 0.10 (es = 0.21) G2/G5: P = 0.001 (es = 0.27) G3/G5: P = 0.005 (es = 0.36) G4/G5: P = 0.003 (es = 0.46)
| | | | Harms: Withdrawn due to inability to tolerate medium or high doses of study drug, test-dose phase, n: 6/72 Withdrawn due to AEs, cross-over phase, n: G1: 1 G2: 3 G3: 3 Adverse effects, n (%): Appetite decrease: G1: 3 (4.6) G2: 16 (24.2) G3: 12 (24.0) G5: 2 (3.0) G2/G5: P ≤ 0.001 G3/G5: P ≤ 0.01 Difficulty falling asleep: G1: 7 (10.6) G2: 12 (18.2) G3: 8 (16.0) G5: 1 (1.5) G1/G5: P ≤ 0.05 G2/G5: P ≤ 0.01 G3/G5: P ≤ 0.05 Stomach or abdominal discomfort: G1: 2 (3.0) G2: 5 (7.6) G3: 6 (12.0) G5: 1 (1.5) Irritability: G1: 5 (7.6) G2: 8 (12.1) G3: 5 (10.0) G5: 2 (3.0) G2/G5: P ≤ 0.05 Emotional outburst: G1: 5 (7.6) G2: 9 (13.6) G3: 5 (10.0) G5: 0 G2/G5: P ≤ 0.01
| | | | Anxiety: G1: 3 (4.6) G2: 1 (1.5) G3: 4 (8.0) G5: 2 (3.0) Depression: G1: 1 (1.5) G2: 3 (4.6) G3: 4 (8.0) G5: 0 Repetitive behaviors and thoughts: G1: 2 (3.0) G2: 4 (6.1) G3: 3 (6.0) G5: 2 (3.0) Self-injury: G1: 1 (1.5) G2: 3 (4.6) G3: 3 (6.0) G5: 2 (3.0) Headache: G1: 2 (3.0) G2: 1 (1.5) G3: 3 (6.0) G5: 0 Diarrhea: G1: 3 (4.6) G2: 3 (4.6) G3: 3 (6.0) G5: 4 (6.1) Social withdrawal: G1: 2 (3.0) G2: 4 (6.1) G3: 2 (4.0) G5: 0 Increased motor activity: G1: 4 (6.1) G2: 1 (1.5) G3: 1 (2.0) G5: 1 (1.5) Bradycardia: G1: 3 (4.6) G2: 0 G3: 0 G5: 4 (6.1)
| | | | Tiredness or fatigue: G1: 1 (1.5) G2: 4 (6.1) G3: 0 G5: 0 Modifiers: No effect of age, IQ, diagnosis, or weight on teacher-rated or parent-rated ABC hyperactivity subscale scores. Response rate by dose, subjects with Asperger or PDD-NOS, n (%): G1: 7/19 (37) G2: 7/19 (37) G3: 6/19 (32) G5: 6/19 (32) G1/G5: P = NS G2/G5: P = NS G3/G5: P = NS Response rate by dose, subjects with autistic disorder, n (%): G1: 13/47 (28) G2: 15/47 (32) G3: 12/47 (25) G5: 6/47 (13) G1/G5: P < 0.001 G2/G5: P < 0.001 G3/G5: P < 0.001 Nonsignificant trend toward moderating effect of diagnosis on effect (P = 0.07). Age group, IQ, weight group, or diagnosis did not moderate treatment effect on SNAP-IV or CYPBOCS-PDD scores.

Comments:

** Subjects randomized during crossover phase

Kim et al., 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Kim et al., 2008^*^ Kim et al., 2009† Country: South Korea Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: Graduate School of Music Therapy, Institute for Communication and Psychology, Aalbord University, Denmark Author industry relationship disclosures: NR Design: RCT, Cross-over design | Intervention: 12 weekly 30 minute improvisational music therapy sessions vs. 12 weekly 30 minute play sessions with toys; half of the children had music therapy first, the others play sessions first (24 sessions total competed over 7–8 months) Music and play therapy sessions conducted by different therapists; sessions were divided into child lead first, then therapist lead second Assessments: Parent and provider report (PDDBI, CARS, Korean PEP-R), clinician direct observation and assessment (ESCS, video coding); frequency & duration of observed behaviors recorded by trained research assistants. Predefined target behaviors were undertaken on selected 4 minute samples taken from the undirected and more directed parts of the session, and from selected sessions (1, 4, 8, 12). Each target behavior was coded during joint engagement episodes. Groups: All participants received music therapy and play therapy G1: music therapy G2: toy play sessions Providers, n: Music therapists: 2 Play therapist: 1 Music therapy graduate students: 3 Treatment manual followed: “semi-flexible treatment manual developed and used for both conditions” | Inclusion criteria:; - DSM-IV criteria for autistic disorder; - no previous music or play therapy experience; - Aged 3–5 years; Exclusion Criteria:; - See inclusion criteria; Age, months ± SD (range): 51.20 ± 12.08 (39–71) Mental age: See IQ under baseline measures Gender, n (%): Enrollment: Male: 13 (87) Female: 2 (13) Follow-up: Male: 10 (100) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referred from Child and Adolescent Psychiatry at Seoul National University Hospital Diagnostic tool/method: Met DSM-IV criteria as well as cutoff on the Korean version of the CARS; ADOS administered for 4/10 children, who all met criteria (Korean version unavailable for earlier 6 participants) Diagnostic category, n (%): Autistic disorder: 10 (100) Other characteristics, n (%): Non-verbal: 5 (50) Verbal: 5 (50) | CARS, mean ± SD (range): 36.10 ± 3.41(32–42.5) Korean PEP-DQ, mean ± SD (range): 70.29 ± 9.97 (60–89) Korean SMS-SQ, mean ± SD (range): 58.84 ± 7.80 (47.40–71) PDDBI score: NR (graphs only) ESCS score: NR (graphs only) | Overall ratings:^*^ PDDBI score: NR (graphs only) ANOVA: scores increase with time P < 0.0001 Communication/ language:^*^ ESCS joint attention score: NR (graphs only) ANOVA: time-group interaction (music therapy more effective than play) P = 0.01 Eye Contact: NR (graphs only) ANOVA: Longer duration in music therapy than play P < 0.0001 Turn-Taking: NR (graphs only) ANOVA: Longer duration in music therapy than play P < 0.0001 Social skills:† Joy, mean ± SD: Duration: G1: 13.28 ± 22.98 G2: 2.81 ± 7.93 G1/G2: P < 0.001 Frequency: G1: 3.00 ± 4.64 G2: 1.02 ± 2.59 G1/G2: P < 0.001 ANOVA: Significant difference between selected sessions (P < 0.01) and undirected and directed parts (P < 0.01)
| Defined protocol followed: NR Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1=G2: 15 N at follow-up: G1=G2: 10 | | | Initiation of engagement by child, frequency, mean ± SD: G1: 3.41 ± 4.98 G2: 0.28 ± 0.71 G1/G2: P < 0.001 ANOVA: Significant difference between selected sessions (P < 0.01) and undirected and directed parts (P = 0.03) Initiation of interaction by therapist, frequency, mean ± SD: G1: 8.05 ± 5.13 G2: 10.05 ± 6.47 G1/G2: P < 0.01 Communication/ language:† Emotional synchronicity, mean ± SD: Duration: G1: 12.18 ± 22.20 G2: 2.44 ± 9.35 G1/G2: P < 0.001 Frequency: G1: 1.91 ± 3.45 G2: 0.38 ± 1.01 G1/G2: P < 0.001 ANOVA: Significant difference between selected sessions (P < 0.001) and undirected and directed parts (P < 0.001) Problem behavior:† Compliant response, frequency, mean ± SD: G1: 4.61 ± 3.22 G2: 4.16 ± 4.00 G1/G2: P < 0.001
| | | | ANOVA: Significant difference between selected sessions (P < 0.05) No response, frequency, mean ± SD: G1: 1.43 ± 1.79 G2: 3.04 ± 2.68 G1/G2: P < 0.001 Harms: NR Modifiers: None of the tested two-and three-way interactions of the predictors were significant for any of the outcomes.

King et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: King et al., 2009 Country: US Practice setting: Academic Intervention setting: Academic Enrollment period: NR Funding: NIH Author industry relationship disclosures: 8 of 13 Abbot Labs (3) Aspect Medical Systems (1) BioMarin (1) Boehringer- Ingelheim (1) Bristol-Myers Squibb (5) Eli Lilly (4) Forest Labs (3) Impax (1) IntegraGen (1) Janssen (4) Johnson & Johnson (3) McNeil (1) Nastech (2) Neuropharm (5) Novartis (1) Otsuka (1) Pfizer (1) Sanofi-Aventis (2) Seaside Therapeutics (2) Shire Pharma (2) Supernus (1) UCB Pharma (2) Wyeth (2) Design: RCT | Intervention: Citalopram 10 mg/5 mL or placebo Dosing: children < 40 kg: 2.5 mg/day increased by 2.5 mg increments until day 43, then increased bi-weekly in 5 mg increments, up to 20 mg/day Children ≥ 40 kg: 2.5 mg dosage increased in weekly intervals until day 36, then increased by 5 mg biweekly up to 20 mg/day; if treating clinician suspected a dose-limiting adverse effect, the dosage could be lowered in 2.5 mg increments Assessments: Two masked clinicians met with participants during each scheduled evaluation. The treating clinician reviewed efficacy ratings, monitored and recorded adverse events. The evaluating clinician was blinded to adverse events and monitored efficacy using CGI-I, CYBOCS-PDD, RBS-R, ABC-C questionnaires. Groups: G1: citalopram G2: placebo Co-interventions held stable during treatment: NR Frequency of contact during study: Baseline and at week 12 Concomitant therapies, n: Sleep medication: NR N at enrollment: G1: 73 G2: 76 N at follow-up: G1: 60 G2: 63 | Inclusion criteria:; - 5 to 17 years old; - Met DSM-IV_TR criteria for autistic disorder, Asperger disorder or PDD-NOS; - CGI-S illness severity rating at least moderate; - Compulsive behaviors score at least moderate on CYBOCS-PDD; Exclusion criteria:; - Rhett disorder; - Child disintegrative disorder; - Seizure within past 6 months; - Weight less than 15 kg; - Medical condition that might interfere with study participation; - Clinically significant abnormal baseline laboratory test results; - History of adverse events or failed treatment while taking two or more SSRIs; - Prior treatment with citalopram or escitalopram oxalate; - Recent initiation of behavior therapy; - History of bipolar disorder or manic episode; - Concomitant treatment with psychotropic medications or medication having known interactions with citalopram; Age, years ± SD (range): G1: 9.1 ± 3.2 (5.0–17.3) G2: 9.6 ± 3.1 (5.1–17.1) Mental age: Non-verbal IQ > 70, n (%): G1: 43 (61.4) G2: 43 (60.6) Gender, n (%): Male: G1: 64 (87.7) G2: 64 (84.2) | Overall ratings: CGI-I score, n (%): 4: G1: 21 (28.8) G2: 22 (28.8) 5: G1: 37 (50.7) G2: 37 (48.7) 6: G1: 14 (19.2) G2: 16 (21.1) 7: G1: 1 (1.4) G2: 1 (1.3) Social skills: ABC-C social withdrawal sub-scale, mean ± SD: G1: 11.4 ± 8.2 G2: 11.1 ± 8.0 Communication/ language: ABC-C inappropriate speech subscale, mean ± SD: G1: 5.3 ± 3.7 G2: 5.0 ± 3.7 Repetitive behavior: CYBOCS-PDD, mean ± SD: G1: 15.1 ± 1.8 G2: 15.0 ± 2.1 RBS-R subscale, mean ± SD: Compulsive G1: 7.0 ± 5.4 G2: 5.9 ± 4.3 Restrictive: G1: 4.7 ± 2.8 G2: 4.1 ± 3.0 Ritualistic: G1: 7.0 ± 4.8 G2: 6.9 ± 4.5 Sameness: G1: 11.2 ± 7.4 G2: 10.2 ± 6.9 Self-injurious: G1: 2.8 ± 3.0 G2: 2.6 ± 2.6 | Overall ratings: CGI-I score, 12 weeks, mean: G1: NR^*^ G2: NR^*^ G1+G2/BL: P < 0.001 G1/G2: P = NS Positive response, 12 weeks, %: CGI-I criteria: G1: 32.9 G2: 34.2 G1/G2: P = NS CYBOCS-PPD and CGI-I criteria: G1: 20.6 G2: 13.2 G1/G2: P = NS Social skills: ABC-C social withdrawal subscale, 12 weeks, mean change ± SD: G1: −3.4 ± 6.1 G2: −2.9 ± 5.0 G1/G2: P = NS Communication/ language: ABC-C inappropriate speech subscale, 12 weeks, mean change ± SD: G1: −0.8 ± 2.9 G2: −0.8 ± 2.5 G1/G2: P = NS Repetitive behavior: CYBOCS-PDD, 12 weeks, mean change ± SD: G1: −2.0 ± 3.4 G2: −1.9 ± 2.5 G1/G2: P = NS RBS-R subscale, 12 weeks, mean change ± SD: Compulsive: G1: −1.8 ± 3.9 G2: −1.3 ± 3.2 G1/G2: P = NS
| | Race/ethnicity, n (%): Hispanic: G1: 9 (12.5) G2: 8 (10.5) American Indian or Alaskan native: G1: 0 G2: 2 (2.6) Asian: G1: 6 (8.2) G2: 8 (10.5) Black: G1: 7 (9.6) G2: 10 (13.2) Native Hawaiian: G1: 1 (1.4) G2: 0 White: G1: 53 (72.6) G2: 55 (72.4) Other: G1: 6 (8.2) G2: 4 (5.3) SES: Maternal education: NR Household income: NR Diagnostic approach: In Study Diagnostic tool/method: DSM-IV-TR, ADI-R, ADOS Diagnostic category: See inclusion criteria Other characteristics: Tanner Stage, n (%): 1: G1: 52 (73.2) G2: 48 (63.2) 2: G1: 10 (14.1) G2: 12 (15.8) > 3: G1: 9 (12.7) G2: 16 (21.1) | Stereotyped: G1: 6.8 ± 4.0 G2: 6.1 ± 3.9 ABC-C stereotypy subscale, mean ± SD: G1: 7.2 ± 4.8 G2: 7.2 ± 4.5 Commonly occurring co-morbidities: ABC-C irritability subscale, mean ± SD: G1: 13.2 ± 8.8 G2: 11.2 ± 8.5 ABC-C hyperactivity subscale, mean ± SD: G1: 20.2 ± 11.7 G2: 20.2 ± 11.2 | Restrictive: G1: −0.6 ± 2.6 G2: −0.9 ± 2.5 G1/G2: P = NS Ritualistic: G1: −1.6 ± 3.5 G2: −1.5 ± 3.4 G1/G2: P = NS Sameness: G1: −3.0 ± 6.0 G2: −2.4 ± 5.3 G1/G2: P = NS Self-injurious: G1: −0.4 ± 3.0 G2: −0.7 ± 2.0 G1/G2: P = NS Stereotyped: G1: −1.2 ± 3.2 G2: −1.1 ± 2.7 G1/G2: P = NS ABC-C stereotypy subscale, 12 weeks, mean change ± SD: G1: −0.7 ± 4.5 G2: −1.0 ± 3.3 G1/G2: P = NS Commonly occurring co-morbidities: ABC-C irritability subscale, 12 weeks, mean change ± SD: G1: −3.2 ± 6.5 G2: −0.9 ± 6.0 G1/G2: P = 0.03 ABC-C hyper- activity subscale, 12 weeks, mean change ± SD: G1: −1.6 ± 7.8 G2: −3.1 ± 7.8 G1/G2: P = NS Harms, n (%): Any adverse event: G1: 71 (97.3) G2: 66 (86.8) G1/G2: P = 0.03
| | | | Energy level increased: G1: 28 (38.4) G2: 15 (19.7) G1/G2: P = 0.02 Anger or irritability: G1: 18 (24.7) G2: 13 (17.1) G1/G2: P = 0.31 Aggression or hostility: G1: 17 (23.3) G2: 13 (17.1) G1/G2: P = 0.42 Headache or migraine: G1: 15 (20.5) G2: 10 (13.2) G1/G2: P = 0.28 Restlessness or difficulty settling down: G1: 13 (17.8) G2: 7 (9.2) G1/G2: P = 0.15 Disinhibited, impulsive, or intrusive behavior: G1: 14 (19.2) G2: 5 (6.6) G1/G2: P = 0.03 Silliness: G1: 9 (12.3) G2: 10 (13.2) G1/G2: P = 0.99 Anxiety: G1: 8 (11.0) G2: 9 (11.8) G1/G2: P = 0.99 Mood lability: G1: 7 (9.6) G2: 9 (11.8) G1/G2: P = 0.79 Increased speech: G1: 8 (11.0) G2: 4 (5.3) G1/G2: P = 0.24
| | | | Attention and concentration decreased: G1: 9 (12.3) G2: 2 (2.6) G1/G2: P = 0.03 Hyperactivity: G1: 9 (12.3) G2: 2 (2.6) G1/G2: P = 0.03 Stereotypy: G1: 8 (11.0) G2: 1 (1.3) G1/G2: P = 0.02 Nightmares: G1: 5 (6.8) G2: 0 G1/G2: P = 0.03 Seizures: G1: 2 (2.7) G2: 0 G1/G2: P = NR Diarrhea or loose stools: G1: 19 (26.0) G2: 9 (11.8) G1/G2: P = 0.04 Abdominal discomfort: G1: 13 (17.8) G2: 9 (11.8) G1/G2: P = 0.36 Vomiting or nausea: G1: 14 (19.2) G2: 6 (7.9) G1/G2: P = 0.06 Insomnia: Any: G1: 28 (38.4) G2: 17 (22.4) G1/G2: P = 0.05 Initial, or difficulty falling asleep: G1: 17 (23.3) G2: 7 (9.2) G1/G2: P = 0.03 Midcycle or other: G1: 13 (17.8) G2: 9 (11.8) G1/G2: P = 0.36
| | | | Cold, flu, or other systemic infection: G1: 31 (42.5) G2: 26 (34.2) G1/G2: P = 0.32 Appetite: Decreased: G1: 11 (15.1) G2: 10 (13.2) G1/G2: P = 0.82 Increased: G1: 7 (9.6) G2: 8 (10.5) G1/G2: P = 0.99 Rash: G1: 12 (16.4) G2: 8 (10.5) G1/G2: P = 0.34 Other skin or subcutaneous tissue disorder: G1: 9 (12.3) G2: 1 (1.3) G1/G2: P = 0.01 Fatigue: G1: 10 (13.7) G2: 10 (13.2) G1/G2: P = 0.99 Allergies: G1: 15 (20.5) G2: 11 (14.5) G1/G2: P = 0.39 Cough: G1: 10 (13.7) G2: 5 (6.6) G1/G2: P = 0.18 Any serious adverse event: G1: 1 (1.4) G2: 0 G1/G2: P = 0.49
| | | | Modifiers: Results for primary and secondary outcomes remained consistent when adjusted for dosage, adherence, and relevant baseline characteristics. There was no significant effect of IQ on treatment response.

Comments:

* Data only illustrated graphically.

Laud et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Laud et al., 2009 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: December 2000 to February 2008 Funding: NR Author industry relationship disclosures: NR Design: Case series | Intervention: Intensive Interdisciplinary Feeding Program Behavior therapy – Consisted of systematic meal sessions with individualized behavior protocols involving antecedent and consequence manipulations in the meals Oral motor therapy – Conducted by speech pathologist/occupational therapist used to determine a child’s skill and safety in eating by providing oral exercises Duration: Average: 47 days Frequency: Inpatients (n=23): 3 hrs/day behavioral and 1 hr/day oral therapy 7 days/week Outpatients (n=23): 3 hrs/day behavioral and 1 hr/day oral therapy 5 days/week Assessments: Participant feeding behaviors such as acceptance, refusal behaviors, negative vocalizations, and grams consumed Caregiver assessment measures (conducted upon admission and before discharge) included the CEBI, caregiver satisfaction scores, and follow-up survey Groups: G1: intensive behavioral/ oral therapy | Inclusion criteria:; - ≥3 years of age; - Diagnosis of ASD; Exclusion criteria:; - Discharged early for medical reason making involvement in treatment unsafe or for personal reasons of care giver; Age, years (range): 69 (36–145) Mental age: NR Gender, n (%): Male: 40 (87) Female: 6 (13) Race/ethnicity, n (%): White: 24 (52) African American: 5 (11) Asian: 3 (7) Latinos: 3 (7) American Indian: 1 (2) Other: 10 (22) SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: NR Diagnostic category, n (%): ASD: 46 (100) Other characteristics, n (%): Failure to Thrive: 7 (15.2) GER: 26 (56.6) Food allergies: 8 (17.4) Nissen fundoplication: 7 (15.2) Esophagitis/gastritis/ duodenitis: 22 (23.9) Chronic lung disease: 6 (13.0) Cerebral palsy: 5 (10.9) TEF: 0 Tracheostomy: 0 Cleft palate: 0 | Feeding behaviors: Acceptance, mean %: G1: 15.56 Refusal behaviors, mean rate per trial: G1: 25.00 Negative vocalizetions, mean %: G1: 19.93 Grams consumed, mean: G1: 24.41 Caregiver assessment: CEBI total eating problems score, mean: G1: 107.12 Caregiver satisfaction score, mean: G1: NA | Feeding behaviors: Acceptance, mean %: G1: 91.42, G1/BL: P < 0.000 Refusal behaviors, mean rate per trial: G1: 21 G1/BL: P < 0.007 Refusal behaviors, follow-up survey, years from baseline, n (%): Improved: 1–3: 10/14 (71.4) 3+: 15/15 (100) Same: 1–3: 0/14 3+: 0/15 Worsened: 1–3: 1/14 (7.1) 3+: 0/15 Negative vocalizetions, mean %: G1: 4.45 G1/BL: P < 0.000 Grams consumed, mean: G1: 247.82 G1/BL: P < 0.000 Variety of foods follow-up survey, years from baseline, n (%): Greater: 1–3: 11/14 (78.6) 3+: 8/15 (53.3) Same: 1–3: 1/14 (7.1) 3+: 3/15 (20) Less: 1–3: 0/14 3+: 0/15 Texture of foods follow-up survey, years from baseline, n (%): Higher: 1–3: 4/14 (28.6) 3+: 9/15 (60)
| Provider:; - Main care providers: behavioral therapist, occupational and/or speech pathologist; - Others: gastroenterologist, pediatrician, nurse practitioner, and nutritionist; - Social worker for care providers of children; Measure of treatment fidelity reported: No Measure of inter-rater reliability reported: Yes Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 46 N at follow-up: G1: 29 | Prematurity, n (%): < 32 weeks: 6 (13) 32–38 weeks: 9 (19.6) | | Same: 1–3: 7/14 (50) 3+: 4/15 (26.7) Lower: 1–3: 1/14 (7.1) 3+: 1/15 (6.7) Protocol usage, follow-up survey, years from baseline, n (%): Using: 1–3: 7/14 (50.0) 3+: 5/15 (33.3) Using modified version: 1–3: 3/14 (21.4) 3+: 3/15 (20) Not using: 1–3: 4/14 (28.6) 3+: 6/15 (40) Caregiver Assessment: CEBI total eating problems score, mean: G1: 99.62 G1/BL: P < 0.004 Caregiver satisfaction score, mean: G1: 4.48 Program recommendation, follow-up survey, years, n (%): Yes: 1–3: 12/14 (85.7) 3+: 15/15 (100) Depends: 1–3: 2/14 (14.3) 3+: 0/15 No: 1–3: 0/14 3+: 0/15 Harms: NR Modifiers: NR

Marcus et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Marcus et al., 2009 Country: US Practice setting: Pharmaceutical company Intervention setting: Multi-site clinics Enrollment period: June 2006 to June 2008 Funding: Bristol Myers Sqibb, Otsuka Pharmaceutical Co. Author industry relationship disclosures: 5 of 7 Bristol-Myers Squibb (5) Forest (1) Johnson & Johnson (1) Otsuka (2) Design: RCT, multicenter study Note: See related study Owen et al. 2009 ({#5714}) | Intervention: Aripiprazole, 2 mg/day for week 1, increased to 5 mg/day for week 2 and increased in 5 mg increments until assigned daily dose (5, 10, 15 mg/day) reached Assessments: ABC rated by caregiver at each visit; CGI-severity and improvement rated by clinician at each visit, Yale Brown Obsessive Compulsion Scale (compulsion scale only, weeks 0,4,8), administrator/rater NR; Pediatric QoL Inventory, Caregiver Strain Questionnaire assessed at baseline and week 8. Simpson-Angus Scale, Barnes Akathisia Rating Scale, Abnormal Involuntary Movement Scale used by clinician to rate adverse events Groups: G1a: aripiprazole 5 mg/day G1b: aripiprazole 10 mg/day G1c: aripiprazole 15 mg/day G2: placebo Co-interventions held stable during treatment: All psychotropic medications discontinued prior to study; sleep aids, anti-anxiety medication diphenhydramine, psychotropic medications for acute treatment of unforeseen events, benztropine, propranolol administered at investigators discretion Frequency of contact during study: Weekly clinic visits; telephone contact at week 7 | Inclusion criteria:; - Autistic disorder diagnosis (DSMIV, ADI-R) and demonstrated tantrums, aggression, self-injurious behavior, or combination; - CGI-S score ≥ 4 at screening and baseline; - ABC irritability score ≥ 18 at screening and baseline; - Weight ≥ 15 kg; - Age 6–17 yrs; Exclusion criteria: Current diagnosis of bipolar disorder, psychosis, schizophrenia, major depression, or fragile X syndrome; - Diagnosis of another disorder on the autism spectrum including PDD-NOS, Asperger syndrome, Rett syndrome, or childhood disintegrative disorder; - History of neuroleptic malignant syndrome; - Significant risk for suicide; - Seizure in past year; - History of severe head trauma or stroke; - History or evidence of unstable medical conditions; - Clinically significant lab or diagnostic test result; - Demonstrated resistance to antipsychotic medication or allergy/ hypersensitivity to aripiprazole; - Unstable/inconsistent non-pharmacologic therapies; Age, years ± SD: G1a: 9.0 ± 2.8 G1b: 10.0 ± 3.2 G1c: 9.5 ± 3.1 G2: 10.2 ± 3.1 | Overall ratings: CGI-S score, LOCF, mean (SE): G1a: 5.0 (0.1) (n=44) G1b: 4.9 (0.1) (n=52) G1c: 5.1 (0.1) (n=44) G2: 4.7 (0.1) (n=41) Social skills: ABC lethargy/social withdrawal score, LOCF, mean (SE): G1a: 17.7 (1.4) (n=52) G1b: 16.8 (1.3) (n=59) G1c: 18.9 (1.4) (n=53) G2: 18.0 (1.5) (n=49) Repetitive behavior: ABC stereotypy score, LOCF, mean (SE): G1a: 11.4 (0.8) (n=52) G1b: 11.6 (0.8) (N=59) G1c: 11.6 (0.8) (n=53) G2: 10.7 (0.8) (n=49) Problem behavior: ABC hyperactivity score, LOCF, mean (SE): G1a: 33.1 (1.4) (n=52) G1b: 33.7 (1.3) (n=59) G1c: 32.2 (1.4) (n=53) G2: 31.0 (1.4) (n=49) | Overall ratings: CGI-S, week 8, LOCF, mean change (SE): G1a: −0.9 (0.2) (n=44) G1b: −1.0 (0.1) (n=52) G1c: −1.1 (0.2) (n=44) G2: −0.6 (0.2) (n=41) G1a/G2: P = NS G1b/G2: P ≤ 0.05 G1c/G2: P = ≤ 0.05 Response rate, week 8, n (%) G1a: 29 (55.8) (n=52; P ≤ 0.05) G1b: 29 (49.2) (n=59; P = NS) G1c: 28 (52.8) (n=53; P = NS) G2: 17 (34.7) (n=49; P = NS) Social skills: ABC lethargy/ social withdrawal score, week 8, LOCF, mean change (SE): G1a: −5.8 (1.2) (n=52) G1b: −4.9 (1.1) (n=59) G1c: −7.9 (1.1) (n=53) G2: −5.2 (1.2) (n=49) G1a/G2: P = NS G1b/G2: P = NS G1c/G2: P = NS
| Concomitant therapies, %: Analgesics and antipyretics: G1a: 23.1 G1b: 30.2 G1c: 22.2 G2: 17.6 Anticholinergics: G1a: 3.8 G1b: 1.7 G1c: 9.3 G2: 0 Anxiolytics: G1a: 3.8 G1b: 1.7 G1c: 1.9 G2: 5.9 Hypnotics and sedatives: G1a: 3.8 G1b: 1.7 G1c: 1.9 G2: 3.9 Propranolol: G1a: 3.8 G1b: 0 G1c: 0 G2: 2.0 N at enrollment: G1a: 53 G1b: 59 G1c: 54 G2: 52 N at follow-up: G1a: 44 G1b: 49 G1c: 47 G2: 38 | Mental age: NR1 Gender, n (%): Male: G1a: 47 (88.7) G1b: 50 (84.7) G1c: 50 (92.6) G2: 48 (92.3) Race/ethnicity, n (%): White: G1a: 37 (69.8) G1b: 41 (69.5) G1c: 42 (77.8) G2: 35 (67.3) Black: G1a: 13 (24.5) G1b: 15 (25.4) G1c: 9 (16.7) G2: 13 (25.0) Asian: G1a: 1 (1.9) G1b: 2 (3.4) G1c: 0 G2: 3 (5.8) Other: G1a: 2 (3.8) G1b: 1 (1.7) G1c: 3 (5.6) G2: 1 (1.9) SES: Maternal education: NR Household income: NR Diagnostic approach: In Study Diagnostic tool/method: ADI-R Diagnostic category, %: Autistic disorder: G1: 100 G2: 100 Other characteristics: Weight, kg mean ± SD: G1a: 38.9 ± 18.3 G1b: 44.8 ± 22.4 G1c: 42.2 ± 23.0 G2: 45.6 ± 20.0 | Communication/ language: ABC inappropriate speech score, LOCF, mean (SE): G1a: 5.8 (0.6) (n=52) G1b: 6.8 (0.5) (n=59) G1c: 6.3 (0.5) (n=53) G2: 5.9 (0.6) (n=48) CY-BOCS compulsions score, LOCF, mean (SE): G1a: 13.9 (0.6) (n=52) G1b: 13.5 (0.5) (n=59) G1c: 14.1 (0.5) (n=53) G2: 13.7 (0.6) (n=48) Other: Serum prolactin, ng/mL: G1a: 7.2 G1b: 6.5 G1c: 6.7 G2: 6.9 Weight, kg, mean (SE): G1a: 39.0 (3.1) G1b: 45.2 (2.9) G1c: 42.3 (3.0) G2: 46.3 (3.2) BMI, kg/m^2^, mean (SE): G1a: 20.2 (1.0) G1b: 21.1 (1.0) G1c: 20.8 (1.0) G2: 21.0 (1.1) QTcF interval, milliseconds: mean: G1a: 373.5 G1b: 380.2 G1c: 378.2 G2: 384.6 | Communication/ language: ABC inappropriate speech score, week 8, LOCF, mean (SE): G1a: −2.0 (0.5) (n=52) G1b: −1.8 (0.4) (n=59) G1c: −2.3 (0.4) (n=53) G2: −1.1 (0.5) (n=48) G1a/G2: P = NS G1b/G2: P = NS G1c/G2: P ≤ 0.05 Repetitive behavior: ABC stereotypy score, 8 weeks. LOCF, mean change (SE): G1a: −4.5 (0.68) (n=52) G1b: −4.2 (0.63) (n=59) G1c: −4.5 (0.66) (n=53) G2: −1.8 (0.69) (n=49) G1a/G2: P ≤ 0.005 G1b/G2: P ≤ 0.05 G1c/G2: P ≤ 0.005 Problem behavior: ABC hyperactivity score, 8 weeks, LOCF, mean change(SE): G1a: −14.0 (1.6) (n=52) G1b: −13.3 (1.5) (n=59) G1c: −16.3 (1.6) (n=53) G2: −7.7 (1.7) (n=49) G1a/G2: P ≤ 0.005 G1b/G2: P ≤ 0.05 G1c/G2: P ≤ 0.001
| | Previous psychotropic medication, n (%): Any nervous system: G1a: 24/52 (46.2) G1b: 32/59 (54.2) G1c: 31/54 (57.4) G2: 22/51 (43.1) Any psychotic: G1a: 9/52 (17.3) G1b: 14/59 (23.7) G1c: 10/54 (18.5) G2: 11/51 (21.6) Aripiprazole: G1a: 1/52 (1.9) G1b: 1/59 (1.7) G1c: 2/54 (3.7) G2: 3/51 (5.9) Anxiolytic: G1a: 8/52 (15.4) G1b: 9/59 (15.3) G1c: 10/54 (18.5) G2: 8/51 (15.7) Antidepressant: G1a: 8/52 (15.4) G1b: 6/59 (10.2) G1c: 13/54 (24.1) G2: 3/51 (5.9) Psychostimulant: G1a: 3/52 (5.8) G1b: 11/59 (18.6) G1c: 7/54 (13.0) G2: 5/51 (9.8) | | CY-BOCS compulsions, 8 weeks, LOCF, mean change (SE): G1a: −2.6 (0.5) (n=52) G1b: −2.4 (0.4) (n=59) G1c: −3.2 (0.5) (n=53) G2: −1.7 (0.5) (n=48) G1a/G2: P = NS G1b/G2: P = NS G1c/G2: P ≤ 0.05 Other: Pediatric QoL Inventory combined scales total score, LSQ treatment difference (95% CI): G1a: NR (NS) G1b: NR (NS) G1c: 8.2 (1.2–15.2) Harms: Experienced ≥ 1 harm, safety sample, n (%) G1a: 46/52 (88.5) G1b: 53/59 (89.8) G1c: 46/54 (85.2) G2: 37/51 (75.5) Harms (incidence ≥ 5% in G1a, G1b or G1c and twice G2 rate), n (%): Sedation: G1a: 9 (17.3) G1b: 17 (28.8) G1c: 13 (24.1) G2: 3 (5.9) Tremor: G1a: 4 (7.7) G1b: 7 (11.9) G1c: 6 (11.1) G2: 0 Somnolence: G1a: 4 (7.7) G1b: 5 (8.5) G1c: 5 (9.3) G2: 2 (3.9)
| | | | Drooling: G1a: 2 (3.8) G1b: 8 (13.6) G1c: 5 (9.3) G2: 0 Headache: G1a: 3 (5.8) G1b: 5 (8.5) G1c: 5 (9.3) G2: 2 (3.9) Extrapyramidal disorder: G1a: 2 (3.8) G1b: 4 (6.8) G1c: 6 (11.1) G2: 0 Lethargy: G1a: 4 (7.7) G1b: 3 (5.1) G1c: 3 (5.6) G2: 0 Hypersomnia: G1a: 3 (5.8) G1b: 0 G1c: 2 (3.7) G2: 0 Vomiting: G1a: 5 (9.6) G1b: 12 (20.3) G1c: 5 (9.3) G2: 4 (7.8) Salivary hypersecretion: G1a: 1 (1.9) G1b: 4 (6.8) G1c: 6 (11.1) G2: 1 (2.0) Nausea: G1a: 1 (1.9) G1b: 3 (5.1) G1c: 4 (7.4) G2: 1 (2.0) Abdominal pain upper: G1a: 2 (3.8) G1b: 1 (1.7) G1c: 4 (7.4) G2: 1 (2.0)
| | | | Fatigue: G1a: 2 (3.8) G1b: 13 (22.0) G1c: 10 (18.5) G2: 0 Pyrexia: G1a: 3 (5.8) G1b: 7 (11.9) G1c: 5 (9.3) G2: 0 Thirst: G1a: 3 (5.8) G1b: 1 (1.7) G1c: 1 (1.9) G2: 1 (2.0) Cough: G1a: 8 (15.4) G1b: 4 (6.8) G1c: 0 G2: 2 (3.9) Rhinorrhea: G1a: 2 (3.8) G1b: 5 (8.5) G1c: 1 (1.9) G2: 1 (2.0) Nasal congestion: G1a: 1 (1.9) G1b: 1 (1.7) G1c: 4 (7.4) G2: 1 (2.0) Epistaxis: G1a: 0 G1b: 4 (6.8) G1c: 1 (1.9) G2: 0 Nasopharyngitis: G1a: 6 (11.5) G1b: 5 (8.5) G1c: 5 (9.3) G2: 2 (3.9) Gastroenteritis viral: G1a: 1 (1.9) G1b: 3 (5.1) G1c: 1 (1.9) G2: 0 Upper respiratory tract infection: G1a: 2 (3.8) G1b: 0 G1c: 3 (5.6) G2: 0
| | | | Increased appetite: G1a: 10 (19.2) G1b: 3 (5.1) G1c: 7 (13.0) G2: 2 (3.9) Decreased appetite: G1a: 5 (9.6) G1b: 5 (8.5) G1c: 3 (5.6) G2: 1 (2.0) Rash: G1a: 0 G1b: 3 (5.1) G1c: 1 (1.9) G2: 1 (2.0) Weight increased: G1a: 4 (7.7) G1b: 1 (1.7) G1c: 2 (3.7) G2: 1 (2.0) Enuresis: G1a: 0 G1b: 1 (1.7) G1c: 3 (5.6) G2: 1 (2.0) Other: Serum prolactin, 8 weeks, mean change (ng/mL): G1a: −5.4 G1b: −5.2 G1c: −5.8 G2: 0.9 G1a/G2: P < 0.001 G1a/G2: P < 0.001 G1a/G2: P < 0.001 Weight, 8 weeks, LOCF, mean change (kg) (SE): G1a: 1.3 (0.3) G1b: 1.3 (0.3) G1c: 1.5 (0.3) G2: 0.3 (0.3) G1a/G2: P < 0.05 G1a/G2: P < 0.05 G1a/G2: P < 0.05
| | | | BMI, 8 weeks, LOCF, mean change (kg/m^2^) (SE): G1a: 0.6 (0.2) G1b: 0.6 (0.2) G1c: 0.8 (0.2) G2: 0.2 (0.2) G1a/G2: P = NS G1a/G2: P = NS G1a/G2: P < 0.05 Subjects with clinically relevant (≥7%) body weight gain, 8 weeks, LOCF, %: G1a: 32.7 G1b: 15.3 G1c: 30.2 G2: 8.2 G1a/G2: P < 0.005 G1b/G2: P = NS G1c/G2: P < 0.005 QTcF interval, 8 weeks, mean change (milli-seconds): G1a: −0.8 G1b: −4.5 G1c: −4.4 G2: −2.0 G1a/G2: P = NS G1a/G2: P = NS G1a/G2: P = NS Modifiers: NR

Owen et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Owen et al., 2009 Country: US Practice setting: Pharmaceutical company Intervention setting: Multi-site clinics Enrollment period: June 2006 to February 2008 Funding: Bristol Myers Sqibb, Otsuka Pharmaceutical Co. Author industry relationship disclosures: 8 of 8 Abbott (1) Addrenex (1) Astra Zeneca (1) Bristol Myers Squibb (6) Curemark (1) Forest (1) GlaxoSmithKline (1) Janssen (1) Johnson & Johnson (1) KemPharm (1) Lilly (2) Lundbeck (1) Neuropharm (2) Novartis (1) Organon (1) Otsuka (4) Pfizer (2) Sanofi-Aventis (1) Seaside Pharma (1) Sepracore (1) Shire (1) Solvay (1) Wyeth (1) Design: Double-blind, RCT, permuted block randomization; multicenter study Note: See related study Marcus et al., 2009 | Intervention: An 8 week treatment phase with Aripiprazole, 2 mg/day with target dosage of 5,10, or 15 mg/day (maximum 15 mg/day) Assessments: ABC rated by caregiver at each visit; CGI severity and improvement rated by clinician at each visit, CY- BOCS (compulsion scale only, weeks 0, 4, and 8), administrator/rater NR; Pediatric QoL Inventory, Caregiver Strain Questionnaire assessed at baseline and week 8. Simpson-Angus Scale, Barnes Akathisia Rating Scale, Abnormal Involuntary Movement Scale used by clinician to rate adverse events Groups: G1: aripiprazole G2: placebo Co-interventions held stable during treatment: All psychotropic medications discontinued prior to study; lorazepam or alprazolam, sleep aids, diphenhydramine, benztropine, propranolol administered at investigators discretion Frequency of contact during study: Weekly clinic visits; tele-phone contact at week 7 Concomitant therapies, %: Analgesics/antipyretics: G1: 19.1 G2: 22.0 Hypnotics/sedatives: G1: 2.1 G2: 12.0 N at enrollment:^*^ G1: 47 G2: 51 | Inclusion criteria:; - Autistic disorder diagnosis (DSM-IV, ADI- R) and demon-strated tantrums, aggression, self-injurious behavior, or a combination thereof; - CGI-S score ≥4 at screening and baseline; - ABC irritability score ≥18 at screening and baseline; - Weight ≥15 kg; - Age 6–17 years; Exclusion criteria:; - Current diagnosis of bipolar disorder, psychosis, schizophrenia, major depression, or fragile X syndrome; - Diagnosis of another disorder on the autism spectrum including PDD- NOS, Asperger syndrome, Rett syndrome, or childhood disintegrative disorder; - History of neuroleptic malignant syndrome; - Significant risk for suicide; - Seizure in past year; - History of severe head trauma or stroke; - History or evidence of unstable medical conditions; - Clinically significant lab or diagnostic test result; - Demonstrated resistance to antipsychotic medication or allergy/hypersensitivity to aripiprazole; - Unstable/inconsistent non-pharmacologic therapies; Age 6–17y, mean ± SD: G1: 9.7 ± 3.2 G2: 8.8 ± 2.6 Age 6–12y, n (%): G1: 37 (78.7) G2: 46 (90.2) | Overall ratings:^*^ CGI-S, mean: G1: 4.9 (n=40) G2: 4.8 (n=40) Serum prolactin, ng/ml, mean: G1: 9.8 G2: 6.8 QTcF interval, milliseconds, mean: G1: 377.6 G2: 376.3 Social skills: ABC lethargy/social withdrawal score, mean: G1: 19.9 G2: 18.1 Communication/language: ABC inappropriate speech score, mean: G1: 7.0 G2: 7.0 Repetitive behavior: ABC stereotypy score, mean: G1: 11.9 G2: 10.7 Problem behavior: ABC irritability score, mean: G1: 29.6 G2: 30.8 ABC hyperactivity score, mean: G1: 34.1 G2: 34.7 CY-BOCS score (compulsions only), mean: G1: 12.8 (n=43) G2: 13.7 (n=44) | Overall ratings: CGI-I at week 8, LOCF, efficacy sample, %: Very much/much improved: G1: 67 G2: 16 Minimally improved: G1: 15 G2: 20 No change: G1: 13 G2: 45 Minimally worse: G1: 4 G2: 10 Much/very much worse: G1: 0 G2: 8 CGI-I score, week 8, mean: G1: 2.2 G2: 3.6 G1/G2: P < 0.001 LSQ mean treatment difference (95% CI): −1.4 (−1.9, −1.0) CGI-S, week 8, mean change: G1: −1.2 (n=40) G2: −0.4 (n=40) G1/G2: P < 0.001 LSQ mean treatment difference (95% CI): −0.8 (−1.2, −0.4) Serum prolactin, ng/ml, week 8, mean change: G1: −6.3 G2: 1.6 G1/G2: P < 0.001 Weight gain, week 8, % G1: 28.9 G2: 6.1 G1/G2: P < 0.01
| N at follow-up: G1: 39 G2: 36 | Mental age: NR Gender, n (%): Male: G1 :42 (89.4) G2: 44 (86.3) Race/ethnicity, n (%): White: G1: 32 (68.1) G2: 41 (80.4) Black: G1: 11 (23.4) G2: 7 (13.7) Asian: G1: 2 (4.3) G2: 0 Other: G1: 2 (4.3) G2: 3 (5.9) SES: Maternal education: NR Household income: NR Diagnostic approach: In Study Diagnostic tool/method: ADI-R Diagnostic category, n (%): G1: Autistic disorder: G1: 47 (100) G2: 51 (100) PDD-NOS: G1: 0 G2: 0 Asperger syndrome: G1: 0 G2: 0 Other characteristics: Weight, kg ± SD: G1: 43.9 ± 19.2 G2: 40.6 ± 18.9 | | QTcF interval, milliseconds, week 8, mean change: G1: 0.6 G2: 4.5 G1/G2: P = 0.381 Social skills: ABC lethargy/social withdrawal score, week 8, mean change: G1: −7.9 G2: −6.2 G1/G2: P = NS Communication/language: ABC inappropriate speech score, week 8, mean change: G1: −2.5 G2: −0.4 G1/G2: P < 0.001 LSQ mean treatment difference (95% CI): −2.0 (−3.1, −1.0) Repetitive behavior: ABC stereotypy score, 8 weeks, mean change: G1: −4.8 G2: −2.0 G1/G2: P < 0.001 LSQ mean treatment difference (95% CI): −2.9 (−4.5, −1.2) Problem behavior: ABC irritability score, 8 weeks, mean change: G1: −12.9 G2: −5.0 G1/G2: P < 0.001 LSQ mean treatment difference (95% CI): −7.9 (−11.7, −4.1)
| | | | ABC hyperactivity score, 8 weeks, mean change: G1: −12.7 G2: −2.8 G1/G2: P < 0.001 LSQ mean treatment difference (95% CI): −9.9 (−13.8, −5.9) CY-BOCS (compulsions only), 8 weeks, mean change: G1: −3.8 (n=43) G2: −0.8 (n=44) G1/G2: P < 0.001 LSQ mean treatment difference (95% CI): −3.0 (−4.3, −1.6) Harms : Occurring in ≥5% of any group, n (%): Any AE: G1: 43/47 (91.5) G2: 36/50 (72.0) Headache: G1: 3/47 (6.4) G2: 8/50 (16.0) Somnolence: G1: 8/47 (17.0) G2: 2/50 (4.0) Sedation: G1: 5/47 (10.6) G2: 1/50 (2.0) Drooling: G1: 4/47 (8.5) G2: 0 Tremor: G1: 4/47 (8.5) G2: 0 Diarrhea: G1: 4/47 (8.5) G2: 5/50 (10.0) Vomiting: G1: 7/47 (14.9) G2: 2/50 (4.0) Insomnia: G1: 3/47 (6.4) G2: 4/50 (8.0)
| | | | Aggression: G1: 4/47 (8.0) G2: 1/50 (2.1) Fatigue: G1: 10/47 (21.3) G2: 2/50 (4.0) Pyrexia: G1: 4/47 (8.5) G2: 1/50 (2.0) Upper respiratory tract infection: G1: 1/47 (2.1) G2: 5/50 (10.0) Nasopharyngitis: G1: 2/47 (4.3) G2: 3/50 (6.0) Nasal congestion: G1: 3/47 (6.4) G2: 1/50 (2.0) Increased appetite: G1: 7/47 (14.9) G2: 5/50 (10.0) Enuresis: G1: 3/47 (6.4) G2: 4/50 (8.0) Any EPS event: G1: 7/47 (14.9) G2: 4/50 (8.0) Tremor: G1: 4/47 (8.5) G2: 0 Extrapyramidal disorder: G1: 1/47 (2.1) G2: 0 Muscle rigidity: G1: 1/47 (1.2) G2: 0 Muscle spasms: G1: 0 G2: 1/50 (2.0) Akathisia: G1: 0 G2: 1/50 (2.0) Psychomotor hyperactivity: G1: 1/47 (2.1) G2: 2/50 (4.0) Hypokinesia: G1: 1 (2.1) G2: 0 Hyperkinesia: G1: 0 G2: 1/50 (2.0)
| | | | Modifiers: NR

Panerai et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Panerai et al., 2009 Country: Italy Practice setting: Research center Intervention setting: Residential, clinic, and/or school Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: Prospective cohort study | Intervention: TEACCH in a residential center vs. TEACCH at home and at mainstream schools after a parent psychoeducational training vs. inclusive education in mainstream schools (i.e., treatment as usual, nonspecific program) Duration: 3 years in setting TEACHH residential – In residence education with regular intervals home and no additional school involvement TEACCH home based – Attended mainstream classes with support teacher; psychoeducational training of parents for 4 weeks, then repeated 2 week stays on 6 month basis Assessments: CARS, LAP-R, PEP-R, VABS Groups: G1: TEACCH in a residential center G2: TEACCH parent training G3: inclusive education in mainstream school (no protocol) Provider: G1: Educators with support of the management team (a psychologist, educational coordinator, neurologist, and doctor specializing in normal and special education) | Inclusion criteria:; - Attending primary school; - Evaluated for at least a 3-year period; - Assessment included PEP-R; - Diagnosed with autistic disorder and mental retardation; Exclusion criteria:; - See inclusion criteria; Age, years ± SD: G1: 9.66 ± 2.31 G2: 8.66 ± 2.01 G3: 9.09 ± 2.07 Mental age, months ± SD: G1: 20.63 ± 9.52 G2: 23.69 ± 10.5 G3: 20.4 ± 6.93 Gender, n (%): Male: 34 (100) Female: 0 Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In Study Diagnostic tool/method: DSM-IV, CARS, ADI-R Diagnostic category, n (%): Autism: 34 (100) PDD-NOS: 0 Aspergers: 0 Other characteristics: Severe Mental Retardation n (%): 34 (100) CARS score, mean ± SD: G1: 45.75 ± 5.23 G2: 42.42 ± 2.41 G3: 42.9 ± NR | Overall ratings:^*^ PEP-R composite score, mean ± SD: G1: 43.36 ± 24.36 G2: 54.15 ± 26.46 G3: 46.4 ± 21.9 G1/G2/G3: P = NS VABS composite scale, mean ± SD: G1: 100.72 ± 42.92 G2: 109.69 ± 33.83 G3: 94.8 ± 27.89 G1/G2/G3: P = NS Social skills: VABS socialization score, mean ± SD: G1: 16.1 ± 11.6 G2: 16.23 ± 7.45 G3: 16 ± 5.29 G1/G2/G3: P = NS Communication/language: VABS communication score, mean ± SD: G1: 15.9 ± 14.9 G2: 19.46 ± 11.24 G3: 18.1 ± 10.48 G1/G2/G3: P = NS Problem behavior: VABS maladaptive behaviors score, mean ± SD: G1: 16.18 ± 7.33 G2: 17.92 ± 6.57 G3: 18.5 ± 7.38 G1/G2/G3: P = NS Adaptive behavior: VABS daily living score, mean ± SD: G1: 33.1 ± 12.9 G2: 31.92 ± 11.62 G3: 27.8 ± 11.14 G1/G2/G3: P = NS Motor skills: PEP-R fine motor score, mean ± SD: G1: 8.54 ± 4.18 G2: 9.61 ± 3.69 G3: 9.3 ± 3.8 G1/G2/G3: P = NS | Overall ratings: PEP-R composite score, 3 years, mean ± SD: G1: 57.45 ± 29.76 G2: 69.54 ± 22.54 G3: 49 ± 25.24 G1/BL: P = 0.02 G2/BL: P = 0.022 G3/BL: P = NS G1/G2/G3: P = 0.009 G1/G2: P = NS G1/G3: P = NS G2/G3: P = 0.001 VABS composite score, 3 years, mean ± SD: G1: 127.81 ± 45.07 G2: 155.23 ± 39.89 G3: 109.6 ± 33.52 G1/BL: P = 0.02 G2/BL: P = 0.02 G3/BL: P = NS Composite score with motor skills: G1/G2/G3: P = NS G1/G2: P = NS G1/G3: P = NS G2/G3: P = NS Composite score w/o motor skills: G1/G2/G3: P = 0.038 G1/G2: P = NS G1/G3: P = NS G2/G3: P = 0.01 Social skills: VABS socialization score, 3 years, mean ± SD: G1: 25.5 ± 12.2 G2: 27.46 ± 10.89 G3: 16 ± 6.14 G1/BL: P = 0.02 G2/BL: P = 0.018 G3/BL: P = NS
| G2: Support teacher, specific generalist team (psychologist, doctor specializing in normal and special education, educator-coordinator, educator, social worker, psycho-motor and speech therapists), and parent G3: Support teacher and general education teachers Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies, n: G1: NR G2: NR G3: Outpatient treatments (including psychomotor therapy and speech therapy): NR N at enrollment: G1: 11 G2: 13 G3: 10 N at follow-up: G1: 11 G2: 13 G3: 10 | ADI-R score, mean ± SD: Communication: G1: 15.18 ± 2.79 G2: 14.15 ± 2.76 G3: 13.6 ± 2.01 Social impairment: G1: 27.45 ± 2.8 G2: 24.92 ± 4.54 G3: 26.4 ± 2.55 Repetitive behavior: G1: 7.09 ± 2.43 G2: 7.2 ± 2.65 G3: 6.6 ± 1.78 LAP-R developmental age, months ± SD: Language and literacy: G1: 19.55 ± 9.76 G2: 20.82 ± 8.59 G3: 18.7 ± 6.78 Emotional and social skills: G1: 22.55 ± 9.44 G2: 22.15 ± 6.96 G3: 20.6 ± 6.29 Pre-writing: G1: 22.36 ± 14.47 G2: 26.77 ± 12.79 G3: 26.4 ± 16.11 Self help skills: G1: 29.64 ± 13.9 G2: 31.08 ± 17.69 G3: 27.5 ± 9.08 | PEP-R gross motor score, mean ± SD: G1: 11.45 ± 3.14 G2: 13.23 ± 4.64 G3: 13.4 ± 4.03 G1/G2/G3: P = NS PEP-R eye-hand coordination score, mean ± SD: G1: 4.82 ± 2.89 G2: 5.54 ± 3.53 G3: 4.6 ± 2.95 G1/G2/G3: P = NS VABS motor skills score, mean ± SD: G1: 37.5 ± 7.79 G2: 42.15 ± 10.94 G3: 33.9 ± 8.99 G1/G2/G3: P = NS Educational/cognitive/academic attainment: PEP-R develop- mental age, months ± SD: G1: 20.64 ± 9.52 G2: 23.69 ± 10.55 G3: 20.04 ± 6.93 G1/G2/G3: P = NS PEP-R cognitive performances score, mean ± SD: G1: 4.82 ± 5.47 G2: 7.61 ± 6.2 G3: 6.5 ± 6.04 G1/G2/G3: P = NS PEP-R cognitive verbal performances score ± SD: G1: 2.09 ± 4.99 G2: 2.85 ± 4.08 G3: 0.6 ± 0.07 G1/G2/G3: P = NS Additional: PEP-R imitation score, mean ± SD: G1: 3.45 ± 4.86 G2: 5.77 ± 4.81 G3: 4.1 ± 3.69 G1/G2/G3: P = NS | Total score: G1/G2/G3: P = 0.009 G1/G2: P = NS G1/G3: P = 0.017 G2/G3: P = 0.006 Interpersonal relationships: G1/G2/G3: P = 0.017 G1/G2: P = NS G1/G3: P = 0.035 G2/G3: P = 0.008 Communication/language: VABS communication score, 3 years, mean ± SD: G1: 22.1 ± 16.5 G2: 28.92 ± 16.43 G3: 21.4 ± 11.01 G1/BL: P = 0.05 G2/BL: P = 0.02 G3/BL: P = NS G1/G2/G3: P = NS G1/G2: P = NS G1/G3: P = NS G2/G3: P = NS Problem behavior: VABS maladaptive behaviors score, 3 years, mean ± SD: G1: 12.27 ± 7.04 G2: 17.23 ± 7.35 G3: 24.1 ± 9.69 G1/BL: P = 0.02 G2/BL: P = 0.02 G3/BL: P = NS G1/G2/G3: P = 0.038 G1/G2: P = NS G1/G3: P = 0.032 G2/G3: P = 0.044
| | | PEP-R perception score, mean ± SD: G1: 8 ± 2.76 G2: 9.54 ± 2.47 G3: 7.9 ± 3.66 G1/G2/G3: P = NS | Adaptive behavior: VABS daily living skills score, 3 years, mean ± SD: G1: 42.2 ± 14 G2: 44.85 ± 10.95 G3: 31 ± 12.9 G1/BL: P = 0.02 G2/BL: P = 0.02 G3/BL: P = NS Total: G1/G2/G3: P = 0.033 G1/G2: P = NS G1/G3: P = NS G2/G3: P = 0.009 Personal: G1/G2/G3: P = 0.049 G1/G2: P = NS G1/G3: P = NS G2/G3: P = 0.022 Motor skills: PEP-R fine motor score, 3 years, mean ± SD: G1: 9.82 ± 4.17 G2: 11.46 ± 2.44 G3: 9.3 ± 3.9 G1/BL: P = NS G2/BL: P = 0.024 G3/BL: P = NS G1/G2/G3: P = NS G1/G2: P = NS G1/G3: P = NS G2/G3: P = NS PEP-R gross motor score, 3 years, mean ± SD: G1: 14.1 ± 4.66 G2: 15.8 ± 3.24 G3: 13.8 ± 4.49 G1/BL: P < 0.05 G2/BL: P = 0.018 G3/BL: P = NS G1/G2/G3: P = 0.031 G1/G2: P = NS G1/G3: P = 0.026 G2/G3: P = 0.032
| | | | PEP-R eye-hand coordination score, 3 years, mean ± SD: G1: 6.09 ± 3.11 G2: 7.85 ± 2.82 G3: 5.9 ± 4.77 G1/BL: P = 0.02 G2/BL: P = 0.018 G3/BL: P = NS G1/G2/G3: P = NS G1/G2: P = NS G1/G3: P = NS G2/G3: P = NS VABS motor skills score, 3 years, mean ± SD: G1: 42.1 ± 6.41 G2: 54.08 ± 13.9 G3: 39.4 ± 11.28 G1/BL: P = 0.02 G2/BL: P = 0.02 G3/BL: P = NS G1/G2/G3: P = NS G1/G2: P = NS G1/G3: P = NS G2/G3: P = NS Educational/cognitive/academic attainment: PEP-R developmental age, 3 years, months ± SD: G1: 25.82 ± 12.03 G2: 29.15 ± 10.01 G3: 21.5 ± 8.36 G1/BL: P = 0.02 G2/BL: P = 0.022 G3/BL: P = NS G1/G2/G3: P = 0.005 G1/G2: P = NS G1/G3: P = NS G2/G3: P = 0.005
| | | | PEP-R cognitive verbal performances score, 3 years, mean ± SD: G1: 3.91 ± 5.72 G2: 4 ± 5.07 G3: 1 ± 1.63 G1/BL: P = NS G2/BL: P = NS G3/BL: P = NS G1/G2/G3: P = 0.006 G1/G2: P = NS G1/G3: P = 0.034 G2/G3: P = 0.002 PEP-R cognitive performances score, 3 years, mean ± SD: G1: 8.09 ± 6.59 G2: 10.46 ± 5.62 G3: 5.9 ± 6.04 G1/BL: P = 0.032 G2/BL: P = 0.018 G3/BL: P = NS G1/G2/G3: P = NS G1/G2: P = NS G1/G3: P = NS G2/G3: P = NS Additional: PEP-R imitation score, 3 years, mean ± SD: G1: 5.9 ± 6.12 G2: 8.69 ± 4.4 G3: 4.3 ± 4.14 G1/BL: P < 0.05 G2/BL: P = 0.018 G3/BL: P = NS G1/G2/G3: P = 0.013 G1/G2: P = NS G1/G3: P = NS G2/G3: P = 0.004
| | | | PEP-R perception score, 3 years, mean ± SD: G1: 9.54 ± 3.17 G2: 11.31 ± 1.75 G3: 8.8 ± 3.85 G1/BL: P = NS G2/BL: P = 0.02 G3/BL: P < 0.05 G1/G2/G3: P = NS G1/G2: P = NS G1/G3: P = NS G2/G3: P = NS Harms: NR Modifiers: NR

Piravej, et al. 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Piravej, et al. 2009 Country: Thailand Practice setting: Academic medical center Intervention setting: Clinic Enrollment period: NR Funding: Asia Research Centre, Chulalongkorn University Design: RCT | Intervention: Thai traditional massage (TTM), 2 sessions/week for 8 weeks (1 hour per session) Sessions utilized Just Right Challenge, The Adaptive Response, Actice Engagement, and Child Directed principles of sensory integration Assessments: Conners’ Parent Rating Scales (CPRS) at baseline and 8 weeks; Conners’ Teacher Rating Scales (CTRS) completed by occupational therapist at baseline and 8 weeks Sleep diary completed by parents every week Groups: G1: TTM plus sensory intergration (SI) G2: SI only Provider: Occupational therapist (SI); masseuse for TTM Treatment manual followed: No Defined protocol followed: Yes Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies, n (%): NR N at enrollment: G1: 30 G2: 30 | Inclusion criteria:; - Autism diagnosis made by psychiatrist based on DSM IV criteria; - Age between 3–10 years; - Recruited from rehabilitation center of Thai Red Cross Scoeity; Exclusion criteria:; - Contraindications for TTM including hematologic disorders, fractures, arthritis, joint dislocation, fevers, cardiovascular and pulmonary diseases; - Inability to complete 80% of the treatment program or receive total of 13 massage sessions; - Non-cooperative parents or guardians; Age, mean/yrs ± SD: G1: 4.84 ± 1.86 G2: 4.48 ± 1.80 Gender: G1, n (%): M: 25 (83.3) F: 5 (16.7) G2, n (%): M: 24 (80) F: 6 (20) Race/ethnicity: NR SES: NR Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: DSM-IV Diagnostic category, n (%): Autism: 60 (100) | Problem behavior: CPRS, mean ± SD: Conduct problem: G1: 0.69 ± 0.31 G2: 0.59 ± 0.34 Impulsivity-hyperactivity: G1: 1.62 ± 0.60 G2: 1.65 ± 0.65 Hyperactivity: G1: 1.45 ± 0.51 G2: 1.53 ± 0.48 CTRS, mean ± SD: Conduct problem: G1: 0.98 ± 0.38 G2: 1.11 ± 0.27 Hyperactivity: G1: 1.78 ± 0.46 G2: 2.01 ± 0.34 Inattention-passivity: G1: 1.56 ± 0.41 G2: 1.67 ± 0.27 Hyperactivity index: G1: 1.59 ± 0.49 G2: 1.80 ± 0.36 Educational/cognitive/academic attainment: CPRS, mean ± SD: Learning problem: G1: 1.86 ± 0.55 G2: 2.02 ± 0.56 Commonly occurring comorbidities: CPRS, mean ± SD: Psychosomatic: G1: 0.41 ± 0.45 G2: 0.43 ± 0.34 Anxiety: G1: 0.76 ± 0.53 G2: 0.62 ± 0.49 | Problem behavior: CPRS, mean ± SD: Conduct problem: G1: 0.60 ± 0.26 P = 0.07 G2: 0.63 ± 0.33 P = 0.27 Impulsivity- hyperactivity: G1: 1.44 ± 0.40 P = 0.16 G2: 1.69 ± 0.57 Hyperactivity: G1: 1.32 ± 0.41 P = 0.10 G2: 1.42 ± 0.42 P = 0.27 CTRS, mean ± SD: Conduct problem: G1: 0.64 ± 0.35 P = 0.00 G2: 0.71 ± 0.26 P = 0.00 Hyperactivity: G1: 1.24 ± 0.50 P = 0.00 G2: 1.49 ± 0.37 P = 0.00 Inattention-passivity: G1: 1.18 ± 0.51 P = 0.00 G2: 1.34 ± 0.36 P = 0.00 Hyperactivity index: G1: 1.10 ± 0.49 P = 0.00 G2: 1.28 ± 0.40 P = 0.00 Educational/cognitive/academic attainment: CPRS, mean ± SD: Learning problem: G1: 1.76 ± 0.48 P = 0.38 G2: 1.87 ± 0.53 P = 0.32
| N at follow-up: G1: 30 G2: 30 | Other characteristics: Years since diagnosis, mean ± SD: G1: 2.95 ± 1.79 G2: 2.62 ± 1.79 | Sleep behavior: G1: 11.50 ± 9.23 G2: 13.90 ± 7.67 | Commonly occurring comorbidities: CPRS, mean ± SD: Psychosomatic: G1: 0.41 ± 0.32 P = 0.53 G2: 0.39 ± 0.25 P = 0.50 Anxiety: G1: 0.62 ± 0.56 P = 0.04 G2: 0.73 ± 0.5 P = 0.17 Sleep behavior: G1: 5.33 ± 3.28 P = 0.00 G2: 8.20 ± 6.83 P = 0.00 Comparison of mean differences b/t groups: CPRS, mean difference ± SD: Conduct problem: G1: 0.09 ± 0.27 G2: −0.04 ± 0.23 P = 0.03 Learning problem: G1: 0.10 ± 0.53 G2: 0.15 ± 0.65 P = 0.75 Psychosomatic: G1: −0.01 ± 0.40 G2: 0.03 ± 0.27 P = 0.23 Impulsivity- hyperactivity: G1: 0.17 ± 0.58 G2: −0.03 ± 0.79 P = 0.38 Anxiety: G1: 0.14 ± 0.32 G2: −0.11 ± 0.61 P = 0.01 Hyperactivity: G1: 0.14 ± 0.41 G2: 0.11 ± 0.45 P = 0.60
| | | | CTRS, mean difference ± SD: Conduct problem: G1: 0.33 ± 0.24 G2: 0.39 ± 0.22 P = 0.21 Hyperactivity: G1: 0.54 ± 0.35 G2: 0.52 ± 0.34 P = 0.80 Inattention-passivity: G1: 0.38 ± 0.22 G2: 0.32 ± 0.22 P = 0.28 Hyperactivity index: G1: 0.49 ± 0.26 G2: 0.52 ± 0.29 P = 0.74 Sleep behavior: G1: 6.17 ± 7.14 G2: 5.70 ± 8.56 P = 0.85 Harms NR Modifiers NR

Quirmbach et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Quirmbach et al., 2009 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: RCT | Intervention: Two social stories training sessions one week apart. Baseline and four other trials were completed each day. The last trial was a generalization trial, where games were switched. Assessments: Observation/direct assessment (ADOS, WISC-IV, PIAT-R); observation (turn-taking games 5 times per day in play room): total game playing skill score 0–8, 2 points per skill (greeting behaviors, requesting to play a game, asking another person what they want to play, accepting another’s choice of game) Groups: G1: social story, standard condition (both training days) G2: social story, directive condition (both training days) G3: control story condition unrelated to social skills (control story first day, randomly assigned to either standard or directive story on the second day) G1a: G1 with VCI > 68 G2a: G2 with VCI > 68 G3a: G3 with VCI > 68 G3s: G3a with standard second day G3d: G3a with directive second day Provider: Research assistant Treatment manual followed: NR Defined protocol followed: NR | Inclusion criteria:; - ASD diagnosis; Exclusion criteria:; - Insufficient reading skills (less than first grade level on PIAT-R); Age, yrs ± SD (range): G1: 9.49 ± 2.09 (7–12) G2: 10.33 ± 2.53 (7–14) G3: 8.85 ± 1.59 (7–12) G1a: 9.49 ± 2.04 (7–12) G2a: 9.72 ± 2.61 (7–14) G3a: 8.79 ± 1.38 (7–11) Mental age: See IQ under baseline Gender, n (%): Male: G1: 14 (93) G2: 14 (93) G3: 14 (93) Female: G1: 1 (7) G2: 1 (7) G3: 1 (7) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: NR Diagnostic tool/method: ADOS Diagnostic category, n (%): Autism: 42 (93) ASD: 3 (7) Other characteristics: NR | Overall ratings: ADOS score, mean ± SD: G1: 15.00 ± 4.99 G2: 14.40 ± 3.81 G3: 15.60 ± 4.87 G1a: 11.90 ± 2.42 G2a: 12.60 ± 3.20 G3a: 13.20 ± 2.94 Educational/cog- nitive/academic attainment: WISC-IV score, mean ± SD: FSIQ: G1: 86.20 ± 22.80 G2: 81.00 ± 20.26 G3: 79.47 ± 22.68 G1a: 98.80 ± 16.25 G2a: 91.70 ± 14.87 G3a: 91.50 ± 16.47 VCI: G1: 82.07 ± 28.04 G2: 79.33 ± 24.85 G3: 78.80 ± 27.86 G1a: 98.70 ± 17.32 G2a: 93.50 ± 16.34 G3a: 95.10 ± 17.92 PRI: G1: 99.47 ± 13.83 G2: 95.20 ± 13.18 G3: 90.67 ± 18.89 G1a: 103.20 ± 14.64 G2a: 100.90 ± 8.49 G3a: 97.80 ± 17.12 PIAT-R score, mean ± SD: Reading recognition: G1: 4.09 ± 3.55 G2: 3.66 ± 3.00 G3: 2.49 ± 1.41 G1a: 5.36 ± 3.76 G2a: 4.29 ± 3.51 G3a: 2.96 ± 1.51 Reading comprehension: G1: 3.82 ± 3.72 G2: 3.81 ± 3.72 G3: 2.85 ± 2.50 G1a: 5.00 ± 4.10 G2a: 4.68 ± 4.35 G3a: 3.66 ± 2.74 | Social skills: Total game playing skills score, mean ± SD: Day 1, trial 2: G1: 4.53 ± 3.48 G2: 3.73 ± 2.96 G3: NR G1a: 6.30 ± 2.83 G2a: 5.10 ± 2.60 G3a: NR G3s: 2.40 ± 1.14 G3d: 2.40 ± 1.14 Day 1, trial 3: G1: 4.53 ± 3.25 G2: 4.87 ± 2.90 G3: NR G1a: 6.40 ± 2.07 G2a: 6.30 ± 2.45 G3a: NR G3s: 2.80 ± 1.30 G3d: 2.20 ± 0.84 Day 1, trial 4: G1: 4.07 ± 3.17 G2: 5.07 ± 2.84 G3: NR G1a: 5.90 ±2.03 G2a: 6.40 ± 2.27 G3a: NR G3s: 2.40 ± 1.67 G3d: 2.20 ± 0.84 ANOVA (only trials 1–4): G1/G3: P < 0.05 G2/G3: P < 0.05 Improvement across trials: P < 0.001 G1a/G3a: P < 0.001 G2a/G3a: P < 0.001 Improvement across trials: P < 0.001
Author: Quirmbach et al., 2009 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: RCT | Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 15 G2: 15 G3: 15 G1a: 10 G2a: 10 G3a: 10 G3s: 5 G3d: 5 | | Total game playing skills score, trial 1, mean ± SD: G1: 1.87 ± 1.30 G2: 2.40 ± 1.18 G3: NR G1a: 2.50 ± 0.97 G2a: 2.90 ± 0.88 G3a: NR G3s: 2.80 ± 0.84 G3d: 2.40 ± 0.89 | Day 1, trial 5 (generalization): G1: 3.67 ± 2.82 G2: 4.33 ± 2.66 G3: NR G1a: 5.30 ± 1.77 G2a: 5.70 ± 2.06 G3a: NR G3s: 2.20 ± 1.48 G3d: 2.40 ± 1.14 Day 2, trial 6: G1: 4.53 ± 3.27 G2: 3.93 ± 1.94 G3: NR G1a: 6.50 ± 1.84 G2a: 4.70 ± 1.95 G3a: NR G3s: 3.00 ± 0.71 G3d: 3.00 ± 1.00 Day 2, trial 7: G1: 5.20 ± 3.28 G2: 4.93 ± 3.13 G3: NR G1a: 7.20 ± 1.69 G2a: 6.40 ± 2.63 G3a: NR G3s: 4.80 ± 3.03 G3d: 5.60 ± 1.82 Day 2, trial 8: G1: 5.07 ± 3.31 G2: 4.93 ± 2.99 G3: NR G1a: 7.10 ± 1.66 G2a: 5.90 ± 2.64 G3a: NR G3s: 6.40 ± 2.19 G3d: 4.80 ± 2.17 Day 2, trial 9: G1: 5.07 ± 3.17 G2: 5.80 ± 2.57 G3: NR G1a: 7.00 ± 1.70 G2a: 6.40 ± 1.78 G3a: NR G3s: 6.40 ± 2.19 G3d: 4.60 ± 2.30
Author: Quirmbach et al., 2009 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: RCT | | | | Day 2, trial 10 (generalization): G1: 4.80 ± 3.36 G2: 5.20 ± 2.73 G3: NR G1a: 6.80 ± 1.93 G2a: 6.50 ± 2.27 G3a: NR G3s: 5.40 ± 1.95 G3d: 6.60 ± 1.67 ANOVA (only groups G1 & G2, trials 1–10): G1/G2: P = NS Improvement across trials: P < 0.001 Harms: NR Modifiers: Condition-trial interaction (G1 and G2 improve across trials 1–4, G3 no improvement): P < 0.001 Condition-trial interaction (G1a and G2a improve across trials 1–4, G3a no improvement): P < 0.001 WISC-IV VCI: P < 0.001

Reaven et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Reaven et al., 2009 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: Organization for Autism Research; Doug Flutie Foundation; US DHHS Administration on Developmental Disabilities Author industry relationship disclosures: NR Design: Non-randomized controlled trial | Intervention: 12 weekly 1.5 hour CBT sessions targeting anxiety reduction, including large group time, separate parent and child group meetings, and parent- child dyads Assessment: Two to three 2 hour assessment sessions; diagnostic and developmental batteries (ADOS, SCQ, WASI, K-SADS-PL, SCARED) administered by research team (clinical psychologist with extensive experience in autism, graduate student, postdoctoral fellow) Groups: G1: active treatment G2: waitlist control Provider: Clinicians, parents Measure of treatment fidelity reported: Yes Co-interventions held stable during treatment: No^*^ Concomitant therapies, n (%): Anti-anxiety or antidepressant medications: G1: 5 (50) G2: 9 (39.1) Other psychotropic medications: G1: 4 (40) G2: 13 (56.5) Vitamins and supplements: G1: 6 (60) G2: 20 (87) Restricted diet: G1: 2 (20) G2: 8 (34) | Inclusion criteria:; - Aged 7–14 years; - Diagnosis on the autism spectrum as verified by exceeding the criteria on module III of the ADOS, exceeding the cutoff on the Social Communication Questionnaire, and receiving a current clinical diagnosis of ASD by a licensed clinical psychologist with extensive experience with children with autism; - Overall IQ ≥ 70; - Verbally fluent as evidenced by participation in Module III of the ADOS; - Significant anxiety symptoms (parent report of clinically significant symptoms of a social phobia, separation anxiety, or generalized anxiety on the Kiddie- Schedule for Affective Disorders and Schizophrenia; or exceeding the subscale cutoffs on the SCARED); Exclusion criteria:; - Children with primary symptoms of obsessive-compulsive disorder; - Receiving group or individual therapy focused on anxiety reduction; Age, months ± SD (range): 132.20 ± 22.80 (97–177) Mental age: FSIQ, months ± SD (range): 102.46 ± 16.22 (65–141) Verbal IQ, months ± SD (range): 101.76 ± 19.51 (65–141) Nonverbal IQ, months ± SD (range): 101.76 ± 15.07 (75–144) | Commonly occurring comorbidities: SCARED score, parent report, mean ± SD (range): Total: G1: 32.70 ± 12.21 (20–54) G2: 29.35 ± 10.69 (7–51) Panic symptoms: G1: 4.40 ± 4.2 (0–15) G2: 4.91 ± 4.55 (1–18) Generalized anxiety: G1: 9.94 ± 2.61 (5–13) G2: 9.84 ± 3.82 (3–16) Separation anxiety: G1: 4.92 ± 3.87 (1–13) G2: 5.13 ± 4.39 (0–16) Social anxiety: G1: 9.40 ± 3.12 (5–14) G2: 6.82 ± 5.32 (0–14) School anxiety: G1: 1.80 ± 2.09 (0–7) G2: 2.43 ± 1.94 (0–7) SCARED, child report, mean ± SD (range): Total: G1: 25.67 ± 9.84 (4–34) G2: 26.09 ± 11.99 (3–48) Panic symptoms: G1: 4.67 ± 4.72 (1–15) G2: 6.04 ± 3.67 (0–15) | Commonly occurring co- morbidities: SCARED, parent report, mean ± SD (range) Total: G1: 19.53 ± 8.82 (9–38) G2: 27.33 ± 8.85 (9–52) ANOVA: time (P = 0.01), treatment × time interaction (P = 0.01) Panic symptoms: G1: 2.34 ± 2.54 (0–7) G2: 5.76 ± 4.44 (1–19) Generalized anxiety G1: 6.20 ± 2.86 (2–12) G2: 9.14 ± 3.16 (2–17) Separation anxiety: G1: 2.60 ± 2.63 (0–8) G2: 4.60 ± 2.81 (0–11) Social anxiety: G1: 6.80 ± 2.25 (4–12) G2: 6.57 ± 3.47 (0–14) School anxiety: G1: 1.5 ± 1.95 (0–3) G2: 1.27 ± 1.16 (0–3)
| Number of prescribed medications, n (%): None: 11 (33.3) One: 9 (27.3) Two: 6 (18.2) Three: 2 (6.1) Four: 0 Five: 5 (15.2) Medications, n (detail): Anti-anxiety medication PRN: 2 (1 clonipin; 1 busparone) SSRI: 14 (3 fluvoxamine; 3 fluoxetine; 4 sertraline; 2 paroxetine; 2 citalopram) Trazedone: 3 Mood stability: 4 (1 lithium; 2 depakote; 1 trileptal) Second generation antipsychotics: 6 (3 risperidone; 2 seroquel; 1 abilify) Attention deficit medication: 15 (9 Concerta; 5 Adderall; 1 Tenex) Multivitamins and general nutritional supplements: 21 Omega-3 supplements: 8 N at enrollment: G1: 10 G2: 23 N at follow-up: G1: 10 G2: 21 | Gender, n (%): Male: G1: 7 (70) G2: 19 (82.6) Female: G1: 3 (30) G2: 4 (17.4) Race/ethnicity, n (%): White: G1: 8 (80) G2: 19 (82.6) African American: G1: 1 (10) G2: 1 (4.3) Hispanic: G1: 1 (10) G2: 1 (4.3) Other: G1: 0 G2: 2 (8.6) SES: Maternal education, n (%): High school: G1: 0 G2: 2 (8.7) Some college: G1: 3 (30) G2: 6 (26.1) College graduate: G1: 4 (40) G2: 8 (34.8) Postcollege: G1: 3 (30) G2: 6 (26.1) Missing: G1: 0 G2: 1 (4.3) Household income: NR Diagnostic approach: In Study Diagnostic tool/method: See inclusion criteria Diagnostic category, n (%): Autism: G1: 3 (30) G2: 12 (52.2) PDD-NOS: G1: 2 (20) G2: 2 (8.7) Aspergers: G1: 5 (50) G2: 9 (39.1) | Generalized anxiety: G1: 5.33 ± 4.15 (0–14) G2: 6.23 ± 3.89 (0–14) Separation anxiety: G1: 4 ± 3.87 (0–11) G2: 6.09 ± 3.09 (0–13) Social anxiety: G1: 6.89 ± 3.44 (2–13) G2: 7.23 ± 4.25 (1–14) School anxiety: G1: 2.44 ± 1.87 (0–5) G2: 2.05 ± 1.60 (0–6) Percentage of children in both groups obtaining SCARED scores within the clinically significant range:^**^ Panic: Parent report: 27.3 Child report: 38.7 Generalized: Parent report: 69.7 Child report: 19.4 Separation: Parent report: 54.5 Child report: 51.6 Social: Parent report: 51.5 Child report: 45.2 School: Parent report: 33.3 Child report: 41.9 Total anxiety symptoms: Parent report: 66.7 Child report: 51.6 | SCARED, child report, mean ± SD (range): Total: G1: 20.50 ± 12.69 (1–31) G2: 24.85 ± 16.34 (4–64) ANOVA: time (P = 0.67), treatment × time interaction (P = 0.99) Panic symptoms: G1: 3.33 ± 3.07 (0–8) G2: 5.60 ± 5.94 (0–21) Generalized anxiety: G1: 4.33 ± 2.50 (0–7) G2: 6.45 ± 6.14 (0–16) Separation anxiety: G1: 2.83 ± 2.40 (0–6) G2: 5.90 ± 5.14 (0–21) Social anxiety: G1: 6.33 ± 3.72 (0–10) G2: 6.50 ± 4.53 (0–14) School anxiety: G1: 2.83 ± 2.10 (1–6) G2: 0.91 ± 0.03 (0–2) Percentage of children in both groups obtaining SCARED scores within the clinically significant range:^**^ Panic: Parent report: 16 Child report: 17.6 Generalized: Parent report: 8 Child report: 17.6
| | Other characteristics, n (%): Primary anxiety diagnosis: Generalized anxiety: G1: 7 (70) G2: 15 (65.2) Separation anxiety: G1: 2 (20) G2: 4 (17.3) Social anxiety: G1: 1 (10) G2: 4 (17.4) Food allergies and restricted diet: 10 (31.2) | | Separation: Parent report: 24 Child report: 29.4 Social: Parent report: 32 Child report: 47.1 School: Parent report: 16 Child report: 17.6 Total anxiety symptoms: Parent report: 28 Child report: 41.2 Harms: NR Modifiers: NR

Comments:

* 1 child in G1 was placed on a different mood stabilizer and 2 children in G2 received higher doses of medicine for attentional difficulties; data on changes in therapy not available for 13 participants.

** Chi-square analyses for the entire sample on pretreatment and post-treatment assessments indicated significant differences in clinical classification for parent report (P = 0.03), but not for child report (P = 0.48).

Reed et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Reed et al., 2009 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: None Design: Case series, prospective | Intervention: Parent-based sleep education workshops, each workshop consisted of 3 sessions conducted over 3 consecutive weeks, with each session lasting 2 hours Assessments: Children’s Sleep Habits Questionnaire, Family Inventory of Sleep Habits, Parental Concerns Questionnaire (PCQ), PSI-SF, RBS, sleep diaries completed by parents at baseline and again approximately 1 month after final session of workshop; actigraphy was downloaded at conclusion of each baseline and post- treatment week Groups: G1: sleep education workshop G1a: children who took more than 20 minutes to fall asleep on baseline actigraphy readings G1b: children with night wakings on actigraphy readings Provider: Neurology sleep specialist and a pediatrician with expertise in ASD with assistance from a nurse educator and educational consultant Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: Taking psychotropic medications, n: 6 N at enrollment: G1: 25 | Inclusion criteria:; - Families with children between the ages of 3 and 10 years; - Child with clinical; diagnosis of ASD; - Families expressed that sleep was a concern; Exclusion criteria:; - Primary sleep disorders (e.g., sleep apnea, narcolepsy); - Neurological or medical conditions that may contribute to disordered sleep (e.g., epileptic seizures); Age, years ± SD: 5.8 ± 2.7 Mental age: PPVT receptive language score, mean ± SD: 74.6 ± 25 Gender, n (%): Male: 16 (80) Female: 4 (20) Race/ethnicity, n: White: 15 African-American: 4 Asian: 1 SES: Maternal education: NR Household income: NR Diagnostic approach: In study Diagnostic tool/method: ADOS Diagnostic category, n: Autism: 15 ASD: 5 Other characteristics: Reported sleep concerns, %: Difficulty falling asleep: 75 Night waking: 60 Early morning awakenings: 35 Cosleeping with parents: 35 | Social skills: PCQ social interactions score, mean ± SD: G1: 2.80 ± 0.95 Communication/language: PCQ language use/understanding score, mean ± SD: G1: 3.00 ± 1.12 Repetitive behavior: RBS restricted behavior score, mean ± SD: G1: 5.11 ± 3.6 PCQ score, mean ± SD: Compulsive behavior: G1: 2.20 ± 0.89 Self-stimulatory behavior: G1: 2.47 ± 1.17 Self-injurious behavior: G1: 1.60 ± 0.88 Problem behavior: Children’s Sleep Habits Questionnaire, bedtime resistance score, mean ± SD: G1: 10.50 ± 3.65 PCQ score, mean ± SD: Aggression: G1: 2.15 ± 1.04 Hyperactivity: G1: 3.15 ± 1.04 Mood swings: G1: 2.10 ± 1.02 Adaptive behavior: Family Inventory of Sleep Habits score, mean ± SD: Exercise during the day: G1: 4.25 ± 0.85 | Social skills: PCQ social inter- actions score, mean ± SD: G1: 2.55 ± 0.89 G1/BL: P = NS Communication/language: PCQ language use/understand- ding score, mean ± SD: G1: 2.85 ± 1.04 G1/BL: P = NS Repetitive behavior: RBS restricted behavior score, mean ± SD:^*^ G1: 3.89 ± 3.1 G1/BL: P = 0.007 PCQ score, mean ± SD: Compulsive behavior: G1: 1.80 ± 0.83 G1/BL: P = NS Self-stimulatory behavior: G1: 2.05 ± 0.91 G1/BL: P = 0.021 Self-injurious behavior: G1: 1.45 ± 0.69 G1/BL: P = NS Problem behavior: Children’s Sleep Habits Questionnaire, bedtime resistance score, mean ± SD: G1: 8.45 ± 2.84 G1/BL: P = 0.001 PCQ score, mean ± SD: Aggression: G1: 1.95 ± 0.94 G1/BL: P = NS Hyperactivity: G1: 2.60 ± 0.99 G1/BL: P = NS
| N at follow-up: G1: 20 | Sleep problems present since birth: 50 Sleep problems occurring around the time of the autism diagnosis: 50 | Wakes up about same time each day: G1: 3.70 ± 0.86 Relaxing activities before bed: G1: 2.95 ± 1.19 Goes to bed at same time each night: G1: 3.94 ± 1.16 Follow regular bedtime routine: G1: 3.39 ± 1.24 PCQ attention span score, mean ± SD: G1: 2.90 ± 0.79 Commonly occurring co- morbidities: Children’s Sleep Habits Questionnaire score, mean ± SD: Sleep onset delay: G1: 2.30 ± 0.80 Sleep duration: G1: 6.53 ± 2.22 Sleep anxiety: G1: 7.00 ± 2.27 Night wakings: G1: 5.55 ± 1.90 Daytime sleepiness: G1: 13.95 ± 4.32 Modified total: G1: 28.63 ± 6.15 Total score: G1: 56.63 ± 9.21 Family Inventory of Sleep Habits score, mean ± SD: Napping during the day: G1: 1.95 ± 1.00 Bedroom used for “time out” during day: G1: 1.15 ± 0.37 | Mood swings: G1: 1.85 ± 0.93 Adaptive behavior: Family Inventory of Sleep Habits score, mean ± SD: Exercise during the day: G1: 4.50 ± 0.69 G1/BL: P = NS Wakes up about same time each day: G1: 4.05 ± 0.22 G1/BL: P = NS Relaxing activities before bed: G1: 4.05 ± 0.60 G1/BL: P = 0.001 Goes to bed at same time each night: G1: 4.06 ± 0.87 G1/BL: P = NS Follow regular bedtime routine: G1: 4.17 ± 0.79 G1/BL: P = 0.022 PCQ attention span score, mean ± SD: G1: 2.95 ± 0.76 G1/BL: P = NS Commonly occurring co- morbidities: Children’s Sleep Habits Questionnaire score, mean ± SD: Sleep onset delay: G1: 1.50 ± 0.61 G1/BL: P = 0.004 Sleep duration: G1: 4.79 ± 2.07 G1/BL: P = 0.003 Sleep anxiety: G1: 5.85 ± 1.73 G1/BL: P = 0.022
| | | Bedroom used as play area during the day: G1: 3.05 ± 1.23 Caffeine after 5pm: G1: 1.70 ± 0.86 Stimulating activities before bed: G1: 2.60 ± 1.05 Sleeps better with certain sleepwear: G1: 2.22 ± 1.44 Sleeps better with certain sheets: G1: 2.37 ± 1.38 Sleeps better when room certain temperature: G1: 2.44 ± 1.15 Room is dark or dimly lit at bedtime: G1: 4.61 ± 1.04 Room is quiet at bedtime: G1: 4.17 ± 1.15 Has favorite comfort object for sleep: G1: 2.94 ± 1.86 Parent stays in child’s room until sleep: G1: 2.56 ± 1.65 Parent checks on child before he or she falls asleep: G1: 3.11 ± 1.60 Child watches TV, videos, or DVDs to fall asleep: G1: 2.28 ± 1.36 Child listens to music to fall asleep: G1: 2.61 ± 1.46 Parent keeps interactions brief if child awakens: G1: 4.00 ± 1.29 | Night wakings: G1: 4.85 ± 1.79 G1/BL: P = NS Daytime sleepiness: G1: 13.25 ± 3.43 G1/BL: P = NS Modified total: G1: 22.84 ± 5.43 G1/BL: P = 0.000 Total score: G1: 49.74 ± 9.24 G1/BL: P = 0.004 Reported fewer nights of cosleeping, n: 5/7 Reported fewer early morning wakings, n: 1/3 Family Inventory of Sleep Habits score, mean ± SD: Napping during the day: G1: 1.85 ± 0.99 G1/BL: P = NS Bedroom used for “time out” during day: G1: 1.15 ± 0.37 G1/BL: P = NS Bedroom used as play area during the day: G1: 2.60 ± 1.19 G1/BL: P = NS Caffeine after 5pm: G1: 1.50 ± 0.51 G1/BL: P = NS Stimulating activities before bed: G1: 1.80 ± 0.95 G1/BL: P = 0.001 Sleeps better with certain sleepwear: G1: 2.11 ± 1.23 G1/BL: P = NS
| | | Parent returns child to bed if child awakens: G1: 2.82 ± 1.33 Children who took more than 20 minutes to fall asleep on actigraphy readings, n: 9/12 Average time to fall asleep, minutes ± SD: G1a: 62.2 ± 33.3 Problems with night wakings, n: 5/12 Wake time after sleep onset, minutes ± SD: G1b: 5, 24.5 ± 9.8 Time in bed, minutes ± SD: G1: 575.21 ± 53.5 (n=12) PCQ score, mean ± SD: Anxiety: G1: 2.30 ± 0.98 Sleep disturbance: G1: 3.40 ± 0.94 Eating habits: G1: 3.00 ± 1.12 PSI-SF score, mean ± SD: Total: G1: 96.10 ± 23.40 Parental distress: G1: 32.05 ± 11.08 Parent-child interaction: G1: 25.90 ± 6.70 Difficult child: G1: 38.15 ± 8.80 Ease in establishing sleeping/eating schedule: G1: 4.05 ± 1.03 | Sleeps better with certain sheets: G1: 2.47 ± 1.47 G1/BL: P = NS Sleeps better when room certain temperature: G1: 2.50 ± 1.34 G1/BL: P = NS Room is dark or dimly lit at bedtime: G1: 4.78 ± 0.43 G1/BL: P = NS Room is quiet at bedtime: G1: 4.56 ± 0.51 G1/BL: P = NS Has favorite comfort object for sleep: G1: 2.83 ± 1.62 G1/BL: P = NS Parent stays in child’s room until sleep: G1: 1.94 ± 1.30 G1/BL: P = NS Parent checks on child before he or she falls asleep: G1: 2.72 ± 1.32 G1/BL: P = NS Child watches TV, videos, or DVDs to fall asleep: G1: 1.50 ± 1.04 G1/BL: P = 0.004 Child listens to music to fall asleep: G1: 2.17 ± 1.34 G1/BL: P = NS Parent keeps interactions brief if child awakens: G1: 4.46 ± 1.13 G1/BL: P = NS
| | | Medical: Children’s Sleep Habits Questionnaire score, mean ± SD: Parasomnias: G1: 10.50 ± 2.24 Sleep-disordered breathing: G1: 3.42 ± 0.84 Sensory: PCQ sensory issues score, mean ± SD: G1: 2.85 ± 0.99 | Parent returns child to bed if child awakens: G1: 4.36 ± 0.67 G1/BL: P = NS Average time to fall asleep, minutes ± SD: G1a: 45.6 ± 27.6 G1/BL: P = 0.039 Problems with reported improvement in night wakings, n: Actigraphy and parent report: 2/5 Parent report only: 1/5 Wake time after sleep onset, minutes ± SD: G1b: 32.2 ± 24.7 Time in bed, minutes ± SD: G1: 541.91 ± 36.2 (n=12) G1/BL: P = 0.039 PCQ score, mean ± SD: Anxiety: G1: 2.05 ± 0.94 G1/BL: P = NS Sleep disturbance: G1: 2.20 ± 1.01 G1/BL: P = 0.000 Eating habits: G1: 2.70 ± 1.26 G1/BL: P = NS PSI-SF score, mean ± SD: Total: G1: 94.00 ± 23.00 G1/BL: P = NS Parental distress: G1: 31.10 ± 10.58 G1/BL: P = NS Parent-child interaction: G1: 26.50 ± 8.58 G1/BL: P = NS
| | | | Difficult child: G1: 36.40 ± 7.79 G1/BL: P = NS Ease in establishing sleeping/eating schedule: G1: 3.32 ± 1.33 G1/BL: P = 0.021 End of workshop parent survey, n (%): Presenters competent and knowledgeable, 18/18 (100) Would recommend workshop: 18/18 (100) Believed child’s sleep habits improved: 14/18 (77) Conveying of information relevant and useful: 17/18 (94) Total duration of workshop sufficient: 10/18 (58) Medical: Children’s Sleep Habits Questionnaire score, mean ± SD: Parasomnias: G1: 10.05 ± 2.37 G1/BL: P = NS Sleep-disordered breathing: G1: 3.32 ± 0.75 G1/BL: P = NS Sensory: PCQ sensory issues score, mean ± SD: G1: 2.70 ± 0.73 G1/BL: P = NS Harms: NR
| | | | Modifiers: The PPVT receptive language score did not correlate significantly with either the total or modified total Children’s Sleep Habits Questionnaire score

Comments:

* The authors reported no improvement on other subscales of the RBS.

Rossignol et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Rossignol et al., 2009 Country: US Practice setting: Specialty Intervention setting: Clinic Enrollment period: NR Funding: International Hyperbarics Association Author industry relationship disclosures: 8 of 11 Clinicians deriving revenue from hyperbaric treatment (8) International Hyperbaric Association (3) OxyHealth (1) Design: Prospective RCT (Double-blind, Rx in parallel groups) | Intervention: 40 sessions of 1 hour- long hyperbaric treatments at 1.3 atm and 24% oxygen Controls received 40 hour-long treatments in slightly pressurized air (1.03 atm) and 21% oxygen Groups: G1: hyperbaric treatment G2: control Assessments: ABC, ATEC, CGI Co-interventions held stable during treatment: Yes Frequency of contact during study: 40 sessions for each group: twice a day, 5 days/week for 4 consecutive weeks Concomitant therapies, n (%): Nutritional supplements, medications: G1: 23/33 G2: 20/29 ABA therapy: G1: 15/33 G2: 11/29 Medications: G1: 16/33 G2: 10/29 G1/G2: P = NS Children not allowed to begin new or terminate ongoing therapies during the study N at enrollment: G1: 33 G2: 29 N at follow-up: G1: 29 G2: 26 | Inclusion criteria:; - Autistic disorder; - Ages 2–7 years; - No previous hyperbaric treatment; Exclusion criteria:; - Aspergers, PDD-NOS; - Seizure disorder, current ear infection, uncontrolled asthma, inability to equalize ear pressure, fragile X, ongoing chelation treatment; Age, yrs ± SD (range): Total: 4.92 ± 1.21 (2–7) G1: 4.97 ± 1.29 (NR) G2: 4.86 ± 1.13 (NR) Mental age, mean/yrs (range): NR Gender, n (%): Male: G1: 30 (90.9) G2: 22 (75.9) Female: G1: 3 (9.1) G2: 7 (24.1) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral diagnosis of autistic disorder Diagnostic tool/method: ADOS and ADI-R, plus DSM-IV criteria Diagnostic category, n (%): Autism: 62 (100) PDD-NOS: 0 Aspergers: 0 Other characteristics: NR | Overall ratings: ABC total score, mean ± SD: G1: 55.2 ± 28.7 G2: 53.3 ± 24.0 ATEC total score, mean ± SD: G1: 75.3 ± 19.5 G2: 75.6 ± 21.0 Social skills: ABC social withdrawal score, mean ± SD: G1: 10.5 ± 6.9 G2: 11.2 ± 6.9 ATEC sociability score, mean ± SD: G1: 17.4 ± 6.6 G2: 17.8 ± 6.2 Communication/language: ABC speech score, mean ± SD: G1: 3.4 ± 3.1 G2: 3.6 ± 3.6 ATEC speech/language/communication score, mean ± SD: G1: 16.3 ± 5.0 G2: 15.9 ± 6.1 Repetitive behavior: ABC stereotypy score, mean ± SD: G1: 7.5 ± 4.9 G2: 6.2 ± 4.7 Problem behavior: ABC irritability score, mean ± SD: G1: 13.2 ± 9.5 G2: 12.2 ± 7.9 ABC hyperactivity score, mean ± SD: G1: 20.7 ± 9.9 G2: 20.1 ± 8.2 | Overall ratings: CGI score, clinician-rated, mean ± SD: G1: 2.87 ± 0.78 G2: 3.62 ± 0.75 G1/BL: P = 0.0008 G2/BL: P = NS CGI score, clinician-rated, n (%): 1 or 2: G1: 9/30 (30) G2: 2/26 (7.7) (P = 0.0471) 1/2/3: G1: 24/30 (80) G2: 10/26 (38) (P = 0.0024) 4/5: G1: 6/30 (20) G2: 16/26 (62) (P = 0.0024) 5: G1: 0 G2: 2/26 (7.7) G1/G2: P = 0.211 Significant improvement in G1 compared to G2 in CGI subscales, Receptive language (P < 0.0001), social interaction (P = 0.0473), eye contact (P = 0.01) & activity level (P = 0.05). CGI score, parent-rated, mean ± SD: G1: 2.7 ± .81 G2: 3.17 ± .73 G1/BL: P = 0.0336 G2/BL: P = NS
| | | Sensory: ATEC sensory/cognitive awareness score, mean ± SD: G1: 18.1 ± 5.2 G2: 19.6 ± 5.6 Medical: ATEC health/physical/behavioral score, mean ± SD: G1: 23.5 ± 11.5 G2: 22.4 ± 8.3 | CGI score, parent-rated, n (%): 1, 2 or 3: G1: 27/30 (90) G2: 19/26 (73) G1/G2: P = NS More children improved in G1 compared to G2 in parent-rated CGI receptive language (P = 0.02) and eye contact (P = 0.03) ABC total score, mean ± SD: G1: 46.4 ± 24.7 G2: 45.5 ± 17.3 G1/G2: P = NS G1/BL: P = 0.01 G2/BL: P = NS ATEC total score, mean ± SD: G1: 65.9 ± 16.4 G2: 70.1 ± 21.9 G1/G2: P = NS G1/BL: P = 0.002 G2/BL: P = 0.04 Social skills: ABC social withdrawal score, mean ± SD: G1: 9.3 ± 6.7 G2: 8.9 ± 5.6 G1/G2: P = NS G1/BL: P = NS G2/BL: P = NS ATEC sociability score, mean ± SD: G1: 14.5 ± 6.5 G2: 16.0 ± 6.8 G1/G2: P = NS G1/BL: P = 0.0009 G2/BL: P = 0.01
| | | | Communication/language: ABC speech score, mean ± SD: G1: 2.6 ± 2.5 G2: 3.3 ± 3.2 G1/G2: P = NS G1/BL: P = 0.02 G2/BL: P = NS ATEC speech/language/communication score, mean ± SD: G1: 15.5 ± 5.1 G2: 15.4 ± 6.6 G1/G2: P = NS G1/BL: P = NS G2/BL: P = NS Repetitive behavior: ABC stereotypy score, mean ± SD: G1: 6.2 ± 5.1 G2: 5.4 ± 4.0 G1/G2: P = NS G1/BL: P = 0.01 G2/BL: P = NS Problem behavior: ABC irritability score, mean ± SD: G1: 10.5 ± 7.4 G2: 11.3 ± 6.4 G1/G2: P = NS G1/BL: P = 0.01 G2/BL: P = NS ABC hyperactivity score, mean ± SD: G1: 17.8 ± 9.2 G2: 16.8 ± 7.7 G1/G2: P = NS G1/BL: P = 0.02 G2/BL: P = NS
| | | | Medical: ATEC health/physical/behavioral score, mean ± SD: G1: 20.8 ± 8.7 G2: 20.2 ± 7.3 G1/G2: P = NS G1/BL: P = 0.04 G2/BL: P = NS Sensory: ATEC sensory/cognitive awareness score, mean ± SD: G1: 15.1 ± 3.9 G2: 18.5 ± 6.2 G1/G2: P = 0.04 G1/BL: P = 0.002 G2/BL: P = NS Harms: Increased asthma in one participant, but not associated with study. Increased urine frequency and skin rash in one child. Anxiety in one child. In control group, one child with abdominal distension and diarrhea, one with worsened eczema Modifiers: Children’s age: More improvement in ABC total score for children over age five (P = 0.048)
| | | | Children in G1 over age five showed more improvement in ABC irritability (P = 0.015), social withdrawal (P = 0.009), and stereotypy (P = 0.04), and ATEC social-bility (P = 0.01) and sensory/cognitive awareness (P = 0.04). For children age five and under, there was no significant difference between groups. No significant age difference was observed with either parental or physician CGI scale. Autism severity: Children in G1 with baseline ADOS below the 50th percentile showed improvement in ABC irritability (P = 0.03) and stereotypy (P = 0.04), and ATEC social-bility (P = 0.03). For children above the 50^th^ percentile, there was no significant difference between groups. No significant autism severity difference was observed with either parental or physician CGI scale

Silva et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Silva et al., 2009 Country: US Practice setting: Academic Intervention setting: School/home Enrollment period: NR Funding: Curry Stone Foundation Author industry relationship disclosures: NR Design: RCT Note: See related papers Silva et al., 2007, 2008 ({#302; #58}) | Intervention: Qigong massage treatment (trainers met with families for 20 visits over 5 months, at each visit child receives qigong massage treatment from the therapist and parents receive training and support in the follow- through massage given daily by parent to child) Assessments: PDDBI (questionnaire filled out by parents and teachers), ABC (questionnaire filled out by teacher), Sense and Self- regulation Checklist (parent questionnaire developed by authors) and VABS-II (parents completed selected portions) administered before intervention, immediately after final massage session, and 5 months after the intervention was completed Groups: G1: qigong massage G2: waitlist control Co-interventions held stable during treatment: Yes Frequency of contact during study: 20 training and treatment visits over 5 months Concomitant therapies, n: Early intervention preschools (5–10 hours per week): “majority of children” Oregon’s Regional Program Autism Training Sites preschool program: 4 N at enrollment: G1: 25 G2: 21 | Inclusion criteria:; - Age < 6 years; - Eligible for early intervention services for autism; Exclusion criteria:; - Complicating medical diagnoses or chronic medication; Age, months ± SD (range): G1: 65.2 ± 20.7 (25–117) G2: 53.3 ± 18.7 (27–92) Mental age: NR Gender, n: Male: G1: 19 G2: 18 Female: G1: 6 G2: 3 Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: NR Diagnostic category: Regressive autism: G1: 13 G2: 9 Nonregressive autism: G1: 12 G2: 12 Other characteristics: NR | Overall ratings: ABC score, mean ± SD: G1: 48.5 ± 20.8 G2: 64.3 ± 33.8 G1/G2: P = NS PDDBI autism composite score, mean ± SD: Teacher-rated: G1: NR G2: NR G1/G2: P = NS Parent-rated: G1: 49.3 ± 11.7 G2: NR G1/G2: P < 0.05^*^ Communication/language: PDDBI receptive/expressive social communication abilities composite score, mean ± SD: Teacher-rated: G1: 53.7 ± 9.7 G2: 47.0 ± 13.0 G1/G2: P = NS Parent-rated: G1: 57.5 ± 6.8 G2: 49.0 ± 13.10 G1/G2: P < 0.05^*^ Problem behavior: PDDBI maladaptive behaviors score, mean ± SD: Teacher-rated: G1: 50.9 ± 10.4 G2: 56.5 ± 13.3 G1/G2: P = NS Parent-rated: G1: 56.8 ± 11.5 G2: 59.5 ± 10.7 G1/G2: P = NS Sensory: PDDBI sensory score, mean ± SD: Teacher-rated: G1: NR G2: NR G1/G2: P < 0.01^*^ | Overall ratings: Overall treatment effect: Teacher-rated: MANCOVA:^**^ treatment (P = 0.019; partial η^2^ = 0.316) Parent-rated: MANCOVA:^**^ treatment (P = 0.029; partial η^2^ = 0.412) ABC score, mean ± SD: G1: 33.9 ± 18.6 G2: 59.4 ± 35.4 G1/BL: P < 0.00 G2/BL: P = NS ANCOVA:^**^ treatment (P < 0.003; partial η^2^ = 0.237) PDDBI autism composite score, mean ± SD: Teacher-rated: G1: NR G2: NR ANCOVA:^**^ treatment (P < 0.05; partial η^2^ = 0.109) Parent-rated: G1: 38.5 ± 11.7 G2: NR ANCOVA:^**^ treatment (P < 0.001; partial η^2^ = 0.299) Parent-rated, 5 month follow-up: G1: 38.6 ± 9.9 (n=19)
| N at follow-up: G1: 25 G2: 21 | | Parent-rated: G1: 54.2 ± 9.6 G2: 56.0 ± 9.6 G1/G2: P = NS Sense and Self- regulation Checklist score, mean ± SD: Sense: G1: 16.4 ± 6.2 G2: 19.5 ± 6.1 G1/G2: P = NS Systems: G1: 8.2 ± 3.7 G2: 10.1 ± 4.5 G1/G2: P = NS | Communication/language: Teacher PDDBI PDDBI receptive/expressive social communication abilities composite score, mean ± SD: Teacher-rated: G1: 56.7 ± 9.7 G2: 47.6 ± 12.1 G1/BL: P < 0.01 G2/BL: P = NS ANCOVA:^**^ treatment (P < 0.01; partial η^2^ = 0.182) Parent-rated: G1: 61.1 ± 7.0 G2: 49.2 ± 12.8 G1/BL: P < 0.01 G2/BL: P = NS ANCOVA:^**^ treatment (P < 0.007; partial η^2^ = 0.200) Parent-rated, 5 month follow-up: G1: 59.8 ± 9.2 (n=19) Problem behavior: PDDBI maladaptive behaviors score, mean ± SD: Teacher-rated: G1: 44.0 ± 7.6 G2: 49.7 ± 12.2 G1/BL: P < 0.00 G2/BL: P = 0.01 ANCOVA:^**^ treatment (P = NS) Parent-rated: G1: 45.6 ± 10.8, G2: 57.5 ± 10.4 G1/BL: P < 0.00 G2/BL: P = NS ANCOVA:^**^ treatment (P < 0.0003; partial η^2^ = 0.328)
| | | | Parent-rated, 5 month follow-up: G1: 43.9 ± 8.3 (n=19) Sensory: PDDBI sensory score, mean ± SD: Teacher-rated: G1: NR G2: NR Parent-rated: G1: 46.2 ± 9.1 G2: 55.3 ± 10.0. G1/BL: P < 0.00 G2/BL: P = NS ANCOVA:^**^ treatment (P < 0.005; partial η^2^ = 0.216) Parent-rated, 5 month follow-up: G1: 43.5 ± 9.6 (n=19) Sense and Self-regulation Checklist score, mean ± SD: Sense G1: 10.8 ± 5.6 G2: 18.7 ± 6.6 G1/BL: P < 0.00 G2/BL: P = NS Systems: G1: 4.8 ± 3.3 G2: 10.1 ± 3.4 G1/BL: P < 0.00 G2/BL: P = NS Overall: ANCOVA:^**^ treatment (P < 0.0002; partial η^2^ = 0.346) Harms: NR Modifiers: NR

Comments:

* Computed using Bonferroni adjusted post-hoc ANOVA

** with age in months as the covariate

Vismara et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Vismara et al., 2009 Country: US Practice setting: Academic Intervention setting: Varied including children’s hospital, clinical-research university, private intervention agency and a public school Enrollment period: NR Funding: NIH, gift from anonymous foundation Author industry relationship disclosures: NR Design: Case series | Intervention: Early Start Denver Model (ESDM); incorporates the Denver model (a relationship and play-based developmental intervention) and Pivotal Response Training (ABA application to optimize motivation to increase communication, language, and play skills) Phase I: direct intervention of the ESDM included manualized instruction in the teaching principles, intervention techniques, goal development and data collection methods, and fidelity system (5 months) Phase II: parent coaching of the ESDM included teaching therapists to educate parents on how to carry out the ESDM principles (5 months) Both training phases consisted of an initial baseline session followed by three training conditions, each lasting approximately 5–6 weeks: (i) self- instruction with the training materials using print and video materials provided on a DVD; (ii) a 10 hour didactic training seminar for direct treatment and a 3 hour didactic training seminar for parent coaching; and (iii) four hours of team supervision for specific discussion of each site’s training cases. These three training conditions were provided sequentially to all ten therapists at four sites, two remote via telehealth conferencing | Inclusion criteria:; - Age 12–60 months; - Diagnosis of ASD; - No significant health concerns; - No serious or specific medical, genetic, neurological, or sensory condition; - Parental consent for videotaping; - At least 75% parental attendance if the family continued onto the parent training phase; - No participation in additional services exceeding 10 hours per week during the study; Exclusion criteria:; - See inclusion criteria; Age, months ± SD: G1a: 33 ± 7.3 G1b: 33 ± 7.7 G2a: 33 ± 4.4 G2b: 31 ± 6 Mental age: NR Gender: NR Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: Initially diagnosed by community clinicians independent of this study, confirmed by trained physician or psychologist Diagnostic Tool: DSM-IV, ADOS Diagnostic category, n (%): Autism: 32 (100) | Overall ratings: MSEL developmental age, months ± SD: Receptive language: G1a: 22 ± 13 G1b: 14 ± 9.2 G2a: 15 ± 12.3 G2b: 15 ± 12.8 Expressive language: G1a: 23 ± 10 G1b: 16 ± 6.9 G2a: 13 ± 11 G2b: 14 ± 12.5 ADOS score, module 1, mean ± SD: G1a: 13 ± 4.4 G1b: 15 ± 4.9 G2a: 17 ± 3.9 G2b: 15 ± 5.3 Social skills: Number of words, phase I, mean (SE): G1: 9.5 (4.63) Number of words, phase II, mean ± SD: G2: 22.29 ± 27.13 Number of imitations, mean ± SD: G1: NR G2: 14.57 ± 10.67 Attention score, mean ± SD: G1: NR G2: 3.00 ± 0.75 Social initiations, mean ± SD: G1: NR G2: 2.84 ± 0.45 Therapist treatment fidelity, score, mean (SE): G1a: NR^**^ G1b: NR^**^ Therapist-parent coaching fidelity score, mean (SE): G2a: NR^**^ G2b: NR^**^ | Social skills: Number of words, phase I, mean (SE): G1i: 10.3 (4.63) G1ii: 21.4 (4.63) G1iii: 13.5 (4.63) G1i/BL: P = NS G1i/G1ii: P < 0.01 G1ii/G1iii: P < 0.05 Number of words, phase II, mean ± SD: G2i: 15.5 ± 10.99 G2ii: 20.89 ± 16.1 G2iii: 28.22 ± 23.42 G2i/G2ii/G2iii/BL: P = NS Number of imitations, mean ± SD: G1i: NR G1ii: NR G1iii: NR G2i: 11 ± 8.38 G2ii: 13.56 ± 9.81 G2iii: 8.11 ± 9.83 G1i/G1ii/G1iii/BL: P = NS G2i/G2ii/G2iii/BL: P = NS Attention score, mean ± SD: G1i: NR^**^ G1ii: NR^**^ G1iii: NR^**^ G2i: 3.26 ± 0.66 G2ii: 3.46 ± 0.63 G2iii: 3.54 ± 0.79 G1i/BL: P < 0.05 G1i/G1ii+G1iii: P < 0.05 G1ii/G1iii: P = NS G2i/G2ii/G2iii/BL: P = NS Social initiations, mean ± SD: G1i: NR^**^ G1ii: NR^**^ G1iii: NR^**^ G2i: 3.07 ± 0.51 G2ii: 3.14 ± 0.60 G2iii: 3.13 ± 0.68
| Assessments: MSEL adminisitered at start of study; therapists’ and parents’ fidelity of implementation of the ESDM (all measures of fidelity increased over time), frequency of child social communicative behaviors, CBRS, and therapist satisfaction (conducted once post- intervention) Groups: G1: phase I G2: phase II Ga: live Gb: telehealth Gi: self-instruction Gii: didactic seminar Giii: team supervision Provider(s):; - Psychologists; - SLP; - Autism specialist; - OT; - Case manager; - Program director; - Early childhood special educator; - Behavior specialist; Measure of treatment fidelity reported: Yes Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: Total: 32 N at follow-up: Total: 29 N used for analysis:^*^ G1a: 5 G1b: 5 G2a: 5 G2b: 5 | Other characteristics: NR | Parent fidelity score, mean (SE): G2a: NR^**^ G2b: NR^**^ | G1i/BL: P < 0.05 G1i/G1ii+G1iii: P < 0.05 G1ii/G1iii: P = NS G2i/G2ii/G2iii/BL: P = NS Therapist treatment fidelity, score, mean (SE): G1ai: NR^**^ G1aii: NR^**^ G1aiii: NR^**^ G1bi: NR^**^ G1bii: NR^**^ G1biii: NR^**^ G1a/G1b: P = NS G1i/BL: P < 0.05 G1i/G1ii+G1iii: P = 0.05 G1ii/G1iii: P = NS Therapist-parent coaching fidelity score, mean (SE): G2ai: NR^**^ G2aii: NR^**^ G2aiii: NR^**^ G2bi: NR^**^ G2bii: NR^**^ G2biii: NR^**^ G2a/G2b: P = NS G2i/BL: P < 0.05 G2i/G2ii: P = 0.001 G2ii/G2iii: P = NS Parent fidelity score, mean (SE): G2ai: NR^**^ G2aii: NR^**^ G2aiii: NR^**^ G2bi: NR^**^ G2bii: NR^**^ G2biii: NR^**^ G2a/G2b: P = NS G2/BL: P < 0.05 Harms: NR Modifiers: In phase I, there was a significant relationship between therapist fidelity and both social initiations (P < 0.01) and and attention (P < 0.001) In phase II, there was a significant relationship between parent fidelity and social initiations (P < 0.001), imitations (P < 0.01), and attention (P < 0.001)

Comments:

* Authors report that data related to only one randomly selected child per therapist was used in the analysis; data from 2 children are included in both Phase I and II.

** data only illustrated graphically

Whitingham et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Whitingham et al., 2009 Whitingham et al., 2009† Country: Australia Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: School of Psychology, University of Queensland Author industry relationship disclosures: NR Design: RCT | Intervention: Stepping Stones Triple P Positive Parenting Program: participants in groups of 4–5 based on level of functioning, included parent training, practice and feedback, using strategies including descriptive praise, planned ignoring, comic strip conversations and social stories Assessments: Family background questionnaire; ECBI; parenting scale (7-point likert scale: minimum 1, maximum 7); being a parent scale (6-point likert scale; 1=strongly agree, 6=strongly disagree); PAQ Groups: G1: intervention G2: wait-list control Provider: Probationary psychologists enrolled in clinical psychology program; all attended a two-day workshop and received accreditation in stepping stones Measure of treatment fidelity reported: NR Co-interventions held stable during treatment: NR Concomitant therapies: Professional help sought for child’s emotional or behavioral problems, n: G1: 12 G2: 13 N at enrollment: G1: 29 G2: 30 | Inclusion criteria:; - 2.5 to 4 years old at start of intervention; - Received no other major interventions during the assessment period; - Diagnosed with ASD; Exclusion criteria:; - See Inclusion Criteria; Age, years ± SD: Total: 5.91 ± 1.90 G1: 5.62 ± 1.74 G2: 6.2 ± 2.04 Mental age: NR Gender, n (%): Male: G1: 24 (83) G2: 23 (77) Female: G1: 5 (17) G2: 7 (23) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Independent pediatrician and confirmed in study Diagnostic tool/method: Semi-structured interview based on DSM-IV and Gillberg’s criteria for Asperger syndrome Diagnostic category, n (%): ASD: G1: 11 (38) G2: 11 (37) Autism: G1: 4 (14) G2: 4 (13) Asperger syndrome: G1: 12 (41) G2: 15 (50) ASD-NOS: G1: 2 (7%) G2: 0 | Problem behavior: ECBI intensity score, mean ± SD: G1: 144.14 ± 31.32 G2: 142.19 ± 31.73 ECBI problem score, mean ± SD: G1: 18.06 ± 7.71 G2: 19.72 ± 6.83 Parenting scale score, mean ± SD: Laxness: G1: 2.8 ± 0.76 G2: 2.87 ± 0.75 Over-reactivity: G1: 2.97 ± 0.75 G2: 2.9 ± 0.86 Verbosity: G1: 3.26 ± 0.97 G2: 3.38 ± 0.78 Being a parent scale score, mean ± SD: Efficacy: G1: 25.73 ± 5.35 G2: 26.57 ± 5.35 Satisfaction: G1: 32.85 ± 5.79 G2: 33.43 ± 7.21 PAQ child-referent bad behavior score, mean ± SD:† Internality: G1: 7.26 ± 1.79 G2: 6.82 ± 1.76 Stability: G1: 5.70 ± 1.66 G2: 6.59 ± 1.68 Controllability: G1: 6.30 ± 1.69 G2: 5.86 ± 1.75 PAQ child-referent good behavior score, mean ± SD:† Internality: G1: 6.83 ± 1.37 G2: 6.36 ± 0.90 Stability: G1: 7.04 ± 1.33 G2: 7.00 ± 1.15 Controllability: G1: 7.43 ± 1.27 G2: 6.86 ± 1.67 | Problem behavior: ECBI intensity score, mean ± SD: G1: 121.40 ± 25.28 G2: 148.63 ± 30.33 ES = 0.26, P < 0.001 ECBI problem score, mean ± SD: G1: 11.21 ± 6.77 G2: 18.82 ± 8.32 ES = 0.16, P < 0.002 Parenting scale score, mean ± SD: Laxness: G1: 2.61 ± 0.45 G2: 3.30 ± 0.60 ES = 0.22, P < 0.001 Over-reactivity: G1: 2.11 ± 0.59 G2: 3.01 ± 0.85 ES = 0.25, P < 0.001 Verbosity: G1: 2.51 ±.84 G2: 3.37 ±.84 ES = 0.16, P < 0.01 Being a parent scale score, mean ± SD: Efficacy: G1: 18.79 ± 5.99 G2: 23.30 ± 5.93 Satisfaction: G1: 39.41 ± 6.04 G2: 35.23 ± 7.60 Significant trend, P < 0.05
| N at follow-up: G1: 29 G2: 30 | Other characteristics: Current language abilities (for age), n (%): No language: G1: 1 (3) G2: 4 (13) Little language: G1: 6 (21) G2: 7 (23) Verbal: G1: 22 (76) G2: 19 (63) Current marital status of parents, n: Married: G1: 21 G2: 26 Defacto: G1: 2 G2: 2 Divorced: G1: 2 G2: 1 Separated: G1: 3 G2: 1 Never married/defacto: G1: 1 G2: 0 Family situation, n: Original: G1: 22 G2: 27 Step-Family: G1: 1 G2: 1 Sole Parent: G1: 5 G2: 2 Extended: G1: 1 G2: 0 Both Parents: G1: 15 G2: 20 Relationship of primary participating parent to child, n: Mother: G1: 29 G2: 25 Father: G1: 0 G2: 4 | PAQ child-referent ASD-related behavior score, mean ± SD:† Internality: G1: 7.56 ± 1.34 G2: 7.14 ± 1.25 Stability: G1: 6.87 ± 1.63 G2: 7.00 ± 1.85 Controllability: G1: 5.30 ± 1.64 G2: 4.95 ± 1.84 | PAQ child- referent bad behavior score, mean ± SD:† Internality: G1: 6.17 ± 1.11 G2: 6.95 ± 1.53 Stability: G1: 5.35 ± 1.61 G2: 5.86 ± 1.78 Controllability: G1: 6.91 ± 1.56 G2: 6.59 ± 1.65 PAQ child-referent good behavior score, mean ± SD:† Internality: G1: 6.74 ± 1.48 G2: 6.50 ± 1.18 Stability: G1: 7.22 ± 1.73 G2: 6.86 ± 1.52 Controllability: G1: 7.56 ± 1.50 G2: 7.00 ± 1.60 PAQ child- referent ASD- related behavior score, mean ± SD:† Internality: G1: 7.22 ± 1.35 G2: 6.77 ± 1.11 Stability: G1: 6.26 ± 1.68 G2: 7.27 ± 1.52 Controllability: G1: 5.65 ± 1.72 G2: 5.54 ± 1.53 Harms: NR Modifiers: NR
| | Grandmother: G1: 0 G2: 1

Wood et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Wood et al., 2009 Country: US Practice setting: Academic Intervention setting: School, home Enrollment period: March 2006 to August 2007 Funding: Cure Autism Now Foundation, NIH Author industry relationship disclosures: NR Design: RCT Note: Methodology data extracted from Wood et al. 2009 ({#3618}), where more detailed information can be found | Intervention: Immediate treatment or 3- month wait list Therapists worked with families for 16 weekly sessions, each lasting 90 min (about 30 min with the child and 60 min with the parents/family), implementing a version of the Building Confidence CBT program Assessments: Posttreatment assessments were completed on the final day of treatment or within 1 week of termination; post-waitlist assessments were conducted 3 months after the baseline assessment but before initializing CBT Groups: G1: immediate treatment G2: 3-month waitlist Provider: Four doctoral students in clinical or educational psychology, and one postdoctoral fellow in psychology; therapists received training and weekly supervision Measure of treatment fidelity reported: Yes Co-interventions held stable during treatment: Yes Concomitant therapies, n: Psychiatric medication: NR N at enrollment: G1: 9 G2: 10 N at post-treatment follow-up: G1: 9 G2: 10 | Inclusion criteria:; - Met research criteria for ASD; - Had at least one anxiety disorder; - Psychiatric medication, if used, was at a stable dose prior to intake and throughout the trial; Exclusion criteria:; - IQ less than 70; - Concurrent psychotherapy; Age, years ± SD (range): 9.37 ± 1.42 (7–11) Mental age: NR Gender, n (%): Male: 16 (84) Female: 3 (16) Race/ethnicity, n (%): Caucasian: 10 (53) Asian: 4 (21) Native American/caucasian: 2 (11) Latino/Asian: 1 (5) African American/caucasian: 1 (5) SES: Maternal education: NR Primary parent, college degree, n (%): 15 (79) Household income: NR Diagnostic approach: In Study and Referral Diagnostic tool/method: ADI-R; ADOS – Module 3; a checklist regarding circumscribed interests; review of previous assessment records Diagnostic category, n (%): Autism: 19 (100) Other characteristics: NR | Social skills: SRS total score, mean ± SD (range): G1: 113 ± 18.27 (87–145) G2: 116 ± 30.19 (61–151) SRS T-score ≥ 70, n: G1: 9/9 G2: 9/10 | Social skills: SRS total score, mean ± SD (range): G1: 89 ± 26.39 (53–140) G2: 110.30 ± 29.22 (53–146) G1/G2: P < 0.05 SRS T-score ≥ 70, immediate post-treatment, n: G1: 7/9 G2: 9/10 SRS T-score ≥ 70, 3 months post-treatment, LOCF, n: G1: 4/9 G2: NA SRS social motivation score, mean: G1: NR G2: NR G1/G2: P < 0.05 (favoring G1) SRS social awareness score, mean: G1: NR G2: NR G1/G2: P < 0.05 (favoring G1) SRS social cognition score, mean: G1: NR G2: NR G1/G2: P = 0.10 (favoring G1) SRS autistic mannerisms score, mean: G1: NR G2: NR G1/G2: P = NS
| N at 3-month follow-up: G1: 4 G2: NA | | | Communication/language: SRS social communication score, mean: G1: NR G2: NR G1/G2: P < 0.05 (favoring G1) Harms: NR Modifiers: Post-treatment SRS scores were predicted by ADIS-C/P Clinician’s Rating Scale change scores and baseline SRS total scores (P < 0.01) Post-treatment ADIS-C/P scores were predicted by baseline ADIS- C/P scores and SRS change scores (P < 0.01)

Wood et al., 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Wood et al., 2009 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: September 2004 to December 2007 Funding: Cure Autism Now Foundation, NIH Author industry relationship disclosures: None Design: RCT Note: See follow-up paper with additional participants, Wood et al., 2009 ({#5523}) | Intervention: Building Confidence CBT program (modified) – includes coping skills training followed by in vivo exposure (facing fearful situation repeatedly while using coping skills and remaining in situation until habituation). Hierarchy of fearful situations created and the child moves through the hierarchy. Parent training involves supporting in vivo, positive reinforcement, and using communication skills to encourage independence in daily routines Schedule: 16 weekly sessions each lasting 90 minutes (30 minutes with child; 60 minutes with parents) Assessments: Trained graduate student independent evaluators who were blind to the intervention condition of each family conducted diagnostic interviews before and immediately after intervention or waitlist (ADIS-C/P); MASC, CGI-I Measures were completed over the course of two days; post-treatment assessments were completed on the final day of treatment or within a week of termination; post- waitlist assessments were conducted three months after the baseline assessment but before initiating CBT (readministering all anxiety measures) Groups: G1: CBT program G2: waitlist | Inclusion criteria:; - Met research criteria for diagnosis of autism, Asperger syndrome, or PDD-NOS; - Met research criteria for one of the following: separation anxiety disorder (SAD), social phobia, or obsessive compulsive disorder (OCD); - Not taking any psychiatric medication at baseline or were on a stable dose of psychiatric medication; - If medication was being used, children maintained the same dose throughout the study; Exclusion criteria:; - Verbal IQ less than 70; - Currently in psychotherapy or social skills training, or was receiving behavioral interventions such as applied behavior analysis; - Family was currently in family therapy or a parenting class; - Child began psychiatric medication or changed dose during intervention; - The child or parents appeared unable to participate in the intervention program for any reason; Age, years ± SD: G1: 9.18 ± 1.42 G2: 9.22 ± 1.57 Mental age: NR Gender, n (%): Male: G1: 12 (71) G2: 15 (65) Female: G1: 5 (29) G2: 8 (35) | Commonly occurring comorbidities: ADIS-CSR score, mean ± SD (range): G1: 5 ± 0.68 (4–6) G2: 5.14 ± 0.56 (4–6) Parent MASC score, mean ± SD (range): G1: 71.25 ± 17.07 (36–98) G2: 75.38 ± 12.98 (56–103) Child MASC score, mean ± SD (range): G1: 56.66 ± 16.84 (20–77) G2: 54.69 ± 16.8 (25–85) | Overall ratings: Meeting CGI response criteria, n (%): G1: 13 (92.9) G2: 2 (9.1) G1/G2: P < 0.0001 Commonly occurring co- morbidities: ADIS-CSR score, mean ± SD (range): G1: 2.36 ± 1.15 (1–4) G2: 4.77 ± 0.81 (3–6) G1/G2: P < 0.0001 Parent MASC score, mean ± SD (range): G1: 58.48 ± 14.72 (40–98) G2: 76.57 ± 14.65 (56–103) G1/G2: P < 0.0001 Child MASC score, mean ± SD (range): G1: 46.93 ± 14.76 (27–72) G2: 46.5 ± 15.83 (22–79) G1/G2: P = 0.87 Harms: NR Modifiers: NR
| Provider: Doctoral students in clinical or educational psychology and doctoral-level psychologists Measure of treatment fidelity reported: Yes Co-interventions held stable during treatment: See inclusion/exclusion criteria Concomitant therapies: Psychiatric medication: SSRI: G1: 2 (12) G2: 3 (13) Atypical antipsychotic: G1: 3 (18) G2: 3 (13) Stimulant or atomoxetine: G1: 4 (24) G2: 7 (30) N at enrollment: G1: 17 G2: 23 N at follow-up: G1: 14 G2: 22 | Race/ethnicity, n (%): G1: Caucasian: G1: 8 (47) G2: 11 (48) Latino/Latina: G1: 2 (12) G2: 3 (13) Asian/Pacific Islander: G1: 4 (23) G2: 2 (9) African American: G1: 0 G2: 1 (4) Asian/Caucasian: G1: 1 (6) G2: 1 (4) Asian/Latino: G1: 0 G2: 1 (4) African American/Caucasian: G1: 0 G2: 2 (9) Latino/Caucasian: G1: 1 (6) G2: 1 (4) Middle Eastern/Caucasian: G1: 1 (6) G2: 0 Multiracial (> 3): G1: 0 G2: 1 (4) SES: Parent college graduate, n (%): G1: 12 (71) G2: 13 (60) Household income (n=37 parents), n (%): <$40K: 9 (24.3) $40–90K: 10 (27.1) >$90K: 18 (48.6) Diagnostic approach: In Study Diagnostic tool/method: ADI-R and ADOS
| | Diagnostic category, n (%): Autistic disorder: G1: 9 (53) G2: 11 (48) PDD-NOS: G1: 6 (35) G2: 11 (48) Asperger syndrome: G1: 2 (12) G2: 1 (4) Other characteristics, n (%): Other comorbid diagnoses: ADHD: G1: 9 (53) G2: 15 (65) Dysthymia/MDD: G1: 3 (18) G2: 0 ODD/CD: G1: 2 (12) G2: 6 (26) PTSD: G1: 0 G2: 1 (4) Baseline anxiety disorders: Social phobia: G1: 13 (76) G2: 22 (96) SAD: G1: 8 (47) G2: 16 (70) OCD: G1: 8 (47) G2: 9 (39) GAD: G1: 11 (65) G2: 8 (35) Parent married/re-married: G1: 14 (82) G2: 19 (83)

Yoder and Stone, 2006a, 2006b Yoder and Lieberman, 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Yoder and Stone, 2006a, 2006b Yoder and Lieberman, 2009† Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: January 2000 to March 2003 Funding: NIH Author industry relationship disclosures: NR Design: RCT | Intervention: Two communication interventions: Picture Exchange Communication System (PECS) and Responsive Education and Prelinguistic Milieu Teaching (RPMT), delivered three times/week in 20 minute sessions for 6 months, an average of 60 ± 7.1 sessions (range 33–70) Parents given up to 15 hours of training to complement material covered in the children’s treatment sessions Parent training hours, mean ± SD: G1: 7.9 ± 2.3 G2: 10.6 ± 2.2 G1/G2: P < 0.01 Assessments: Pre-and post-treatment: ESCS-abridged, an unstructured free-play session with an examiner, a measure of turn taking and a free-play session with the primary caregiver Spoken communication assessed at pretreatment, post treatment and at 6- month follow-up period {#487} All assessments were conducted by examiners who were not the children’s therapists Groups: G1: PECS G2: RPMT Provider:; - Master’s level professsionals; - Closely supervised paraprofessionals; Treatment manual followed: Yes | Inclusion criteria:; - Diagnosis of autistic disorder or PDD-NOS; - Age 18–60 months; - Used fewer than 10 words during all of three communication samples; - Passed hearing screenings administered outside of the project; Exclusion criteria:; - Severe sensory/motor deficits; - English not the primary language spoken at home; Age, years ± SD (range): G1: 3.1 ± 0.8 (7.8–4.5) G2: 2.7 ± 0.5 (1.9–3.5) Mental age, months ± SD: Nonverbal: G1: 18.8 ± 4.5 (11.5–26.5) G2: 18.6 ± 3.2 (13–23.5) Verbal: G1: 11.7 ± 3.4 (7–19) G2: 11.9 ± 2.5 (7–19) Gender, n (%): Male: 31 (86) Female: 5 (14) Race/ethnicity, n (%): White: 25 (69) African American: 8 (22) Other: 3(8) SES: Primary parent education, median: 3–4 years of college Parental occupational status, mean ± SD (range): G1: 43 ± 22 (10–87) G2: 51 ± 21 (8–80) Diagnostic approach: Referral Diagnostic tool/method: ADOS Diagnostic category, n (%): Autism: 33 (91.7) PDD-NOS: 3 (8.3) Aspergers: 0 | Communication/language: ESCS, number of requests, mean ± SD: Total: 11.9 ± 7.3 G1: 13 ± 8 G2: 11 ± 6 Unstructured free play, number of requests, mean ± SD: Total: 4.2 ± 9.2 ESCS, number of joint attention initiations, mean ± SD: Total: 2.7 ± 3.5 G1: 3 ± 4 G2: 2 ± 2 Unstructured free play, number of joint attention initiations, mean ± SD: Total: 2.7 ± 4.5 Number of object exchange turns, mean ± SD: Total: 3.7 ± 4.5 G1: 5 ± 5 G2: 2 ± 3 ADOS communication algorithm score, mean ± SD:† G1: 5.79 ± 1.18 G2: 6.35 ± 1.27 G1/G2: P = NS ADOS social algorithm score mean ± SD:† G1: 10.32 ± 2.36 G2: 11.64 ± 1.17 G1/G2: P = 0.038 MSEL expressive language, standard score, mean ± SD:† G1: 19.47 ± 1.26 G2: 21.59 ± 3.36 G1/G2: P = 0.024 | Communication/language: ESCS, number of requests, mean ± SD: Total: 17.7 ± 10.7 G1+G2/BL: P = 0.002 Unstructured free play, number of requests, mean ± SD: Total: 4.5 ± 5.7 G1+G2/BL: P = NS ESCS, number of joint attention initiations, mean ± SD: Total: 4.7 ± 4.8 G1+G2/BL: P = 0.01 Unstructured free play, number of joint attention initiations, mean ± SD: Total: 8 9 ± 0.24 G1+G2/BL: P = 0.02 Number of object exchange turns, mean ± SD: Total: 5.5 ± 4.7 G1+G2/BL: P = 0.008 Number of object exchange turns, mean (SE): G1: 4 (0.81) G2: 7.1 (0.86) G1/G2: P = 0.019 Picture exchanges, mean ± SD:† G1: 3.84 ± 4.5 G2: 1.06 ± 1.3 ANOVA: time (P < 0.001), time × treatment (P < 0.001)
| Defined protocol followed: Yes Measure of treatment fidelity reported: Yes Co-interventions held stable during treatment: NR Concomitant therapies, mean ± SD: {#487} Rx phase: 16.8 ± 22.7 6 months: 34.4 ± 39 P = 0.002 Community based speech therapy, hrs/month, mean ± SD: Rx phase: 7.4 ± 4.2 6 months: 9.3 ± 5.9 P = 0.07 Community based speech therapy, hrs/month, mean change ± SD: G1: 4.0 ± 6.9 G2: − 0.3 ± 5.19 G1/G2: P = 0.05 N at enrollment: G1: 19 G2: 17 N at follow-up: G1: 19 G2: 17 | Other characteristics: IQ, mean ± SD (range): G1: 55 ± 7 (49–67) G2: 54 ± 6 (49–67) Number of words used across ESCS and unstructured free play, mean ± SD (range): G1: 0.6 ± 1 (0–5) G2: 0.4 ± 0.7 (0–2) Number of spoken acts across ESCS and unstructured free play, mean ± SD (range): G1: 1.1 ± 2 (0–6) G2: 0.6 ± 1 (0–4) Number of initiating joint attention in ESCS, mean ± SD (range): G1: 3 ± 4 (0–18) G2: 2 ± 2 (0–7) Number of requests in ESCS, mean ± SD (range): G1: 13 ± 8 (1–26) G2: 11 ± 6 (2–20) Number of object exchanges in turn-taking procedure, mean ± SD (range): G1: 5 ± 5 (0–16) G2: 2 ± 3 (0–8) Parent report of words understood, mean ± SD (range): G1: 108 ± 87 (3–291) G2: 62 ± 49 (1–141) Fidelity of prescription: G1: 2.88 ± 0.09 G2: 2.99 ± 0.17 Other characteristics, mean ± SD (range): Cognitive standard score: 51 ± 5.3 (48–67) Number of different nonimitative words used in SFPE: 0.17 ± 0.56 (0–3) | MSEL receptive language, standard score, mean ± SD:† G1: 19.26 ± 0.45 G2: 19.41 ± 0.51 G1/G2: P = NS IQ (derived from Mullen), mean ± SD:† G1: 50.32 ± 5.2 G2: 51.76 ± 5.41 G1/G2: P = NS Picture exchanges, mean:† G1: 0.05 G2: 0.06 Frequency of nonimitative spoken acts, study entry, mean ± SD: 0.25 ± 0.84 Number of different non-imitative words, study entry, mean ± SD: 0.17 ± 0.56 | Frequency of non-imitative spoken acts, end of Rx, mean ± SD: 2.2 ± 3.9 Number of different non-imitative words, end of Rx, mean ± SD: 1.6 ± 2.8 Frequency of nonimitative spoken acts, 6 months, mean ± SD: 5.5 ± 10.4 P = 0.005 Number of different nonimitative words, 6 months, mean ± SD: 3 ± 5.8 P = 0.001 Frequency of non-imitative spoken acts, end of Rx, adjusted^*^ group mean ± SD: G1: 3.6 ± 4.8 G2: 0.6 ± 4.8 P = 0.03 Number of different non-imitative words, end of Rx, adjusted^*^ group mean ± SD: G1: 2.4 ± 3.6 G2: 0.6 ± 3.6 P = 0.04 Frequency of non-imitative spoken acts, 6 months, adjusted^*^ group mean ± SD: G1: 5.5 ± 3.2 G2: 5.4 ± 3.2 P = 0.96
| | Number of nonimitative spoken communication acts in SFPE: 0.25 ± 0.84 (0–4) Number of communication acts in SFPE: 8.4 ± 10.5 (0–56) Proportion of communication acts that are intentional communication in SFPE: 0.89 ± 0.21 (0–1.0) Proportion of communication acts that are spoken words in SFPE: 0.05 ± 0.18 (0–1.0) | | Number of different nonimitative words, 6 months, adjusted^*^ group mean ± SD: G1: 3.1 ± 2.4 G2: 2.9 ± 2.4 P = 0.93 Harms: NR Modifiers: Baseline ADOS negatively correlated with post-treatment frequency of requests in the ESCS (r = −0.35, P = 0.04) and initiating joint attention in the unstructured free play session (r = −0.40, P = 0.007) Baseline object exchange turns correlated with post-treatment frequency of object exchange turns (r = 0.65, P < 0.001) Baseline initiating joint attention predicted differential treatment effects on post-treatment initiating joint attention (P < 0.001) and differential response to treatments on post-treatment requests in the ESCS (P = 0.003)
| | | | Interaction between initial interest in a variety of objects and treatment (P = 0.01) predicting growth in the number of nonimitative words. Children low in initial object exploration benefited more from RPMT & those high in initial object exploration benefited more from PECS

## 2008

Akhondzadeh et al., 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Akhondzadeh et al., 2008 Country: Iran Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: RCT, double blind, placebo controlled | Intervention: Piracetam, titrated up to 800 mg/day (200 mg/day starting dose with 200 mg increments every 2 days) Risperidone, dosage by weight:; - 10–40 kg: titrated up to 2 mg/day fixed dose (0.5 mg starting dose with 0.5 mg increments in weekly dose for first 3 weeks); - > 40 kg: titrated up to 3 mg/day fixed dose; Duration: 10 weeks Assessments: ABC-C, Extrapyramidal Symptoms Rating Scale administered by blinded rater in clinic Groups: G1: piracetam + risperidone G2: placebo + risperidone Co-interventions held stable during treatment: NA Frequency of contact during study: Ratings at weeks 0, 2, 4, 6, 8, and 10 Concomitant therapies: NR N at enrollment: G1: 20 G2: 20 N at follow-up: G1: 20 G2: 20 | Inclusion criteria:; - Age 3–11 years; - Diagnosis of autism; Exclusion criteria:; - Previously received neuroleptics or any psychotropic drug treatment 6 months prior to recruitment; - Significant active medical problem; - Children without definitive diagnosis of autism as in severe/profound mental retardation; Age, years ± SD (range): G1: 6.9 ± 1.86 (3–11) G2: 6.75 ± 1.8 (3–11) Mental age: NR Gender, n (%): Male: G1: 16 (80) G2: 14 (70) Female: G1: 4 (20) G2: 6 (30) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In-study confirmation Diagnostic tool/method: Semistructured interview with a score of ≥ 6 on the DSM-IV diagnosis criteria and clinical evaluation Diagnostic category, n (%): Autism: 40 (100) Other characteristics, n: Extrapyramidal symptoms: G1: 6 G2: 8 G1/G2: P = 0.74 | Problem behavior: ABC-C total score, mean ± SD: G1: 23.15 ± 5.80 G2: 24.00 ± 8.25 G1/G2: P = 0.70 | Problem behavior: ABC-C total score, week 10, mean change ± SD: G1: −11.9 ± 3.79 G2: −5.15 ± 3.04 G1/G2: P < 0.0001 Harms: Treatment-related AEs, n (%): Constipation: G1: 4 (20) G2: 3 (15) G1/G2: P = NS Nervousness: G1: 1 (5) G2: 2 (10) G1/G2: P = NS Daytime drowsiness: G1: 7 (35) G2: 9 (45) G1/G2: P = NS Morning drowsiness: G1: 11 (55) G2: 8 (40) G1/G2: P = NS Increased appetite: G1: 7 (30) G2: 6 (30) G1/G2: P = NS Dry mouth: G1: 4 (20) G2: 3 (15) G1/G2: P = NS Fatigue: G1: 5 (25) G2: 3 (15) G1/G2: P = NS Loss of appetite: G1: 1 (5) G2: 1 (5) G1/G2: P = NS Modifiers: NR

Allam et al., 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Allam et al., 2008 Country: Egypt Practice setting: Academic Intervention setting: Acupuncture clinic Enrollment period: 9 months (dates NR) Funding: NR Author industry relationship disclosures: NR Design: RCT | Intervention: Language therapy 2 times per week with or without scalp acupuncture 2 times per week for 9 months (cycle of 20 minutes twice weekly for 2 months followed by 2 weeks rest) Groups: G1: language therapy G2: language therapy and acupuncture Provider:; - Same language therapist (blinded) worked with both groups; - Scalp acupuncture performed by physician (specialized pediatric acupuncturist); Assessments: Battery of examinations before and after treatment, including communicative assessment and an Arab language test Co-interventions held stable during treatment: None Frequency of contact during study: Assessments conducted once prior to initiation of therapy and once posttherapy; twice a week during therapy Concomitant therapies: NR N at enrollment: G1: 10 G2: 10 N at follow-up: G1: 10 G2: 10 | Inclusion criteria:; - Age 4–7 years; - Diagnosed with autism according to DSM-IVT criteria; - Diagnosed with autism according to interview with parents using ADI-R; - CARS score ≥ 30; Exclusion criteria:; - See inclusion criteria; Age, years ± SD: G1: 5.5 ± 1.22 G2: 5.5 ± 1.22 Mental age: NR Gender, n: G1, n: Male: G1: 5 G2: 7 Female: G1: 5 G2: 3 Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In Study Diagnostic tool/method: DSM-IV-T, parent-rated ADI-R Diagnostic category, n (%): Autism: 20 (100) Other characteristics, n (%): Delayed language development: 20 (100) | Communication/language: Language evaluation score, mean ± SD: Attention: G1: 1.4 ± 0.9 G2: 1.5 ± 0.8 Receptive semantics: G1: 5.2 ± 3.6 G2: 5.0 ± 2.7 Expressive semantics: G1: 0.9 ± 0.6 G2: 0.7 ± 0.5 Receptive syntax: G1: NR^*^ G2: NR^*^ Expressive syntax: G1: NR^*^ G2: NR^*^ Phonology: G1: NR^*^ G2: NR^*^ Pragmatics: G1: NR^*^ G2: NR^*^ | Communication/language: Language evaluation score, mean ± SD: Attention: G1: 2.8 ± 0.8 G2: 3.1 ± 0.8 G1/BL: P = 0.021 G2/BL: P = 0.001 G1/G2: P = 0.008 Receptive semantics: G1: 7.0 ± 3.8 G2: 9.4 ± 3.1 G1/BL: P = 0.021 G2/BL: P = 0.001 G1/G2: P = 0.034 Expressive semantics: G1: 4.4 ± 3.4 G2: 4.1 ± 3.4 G1/BL: P = 0.031 G2/BL: P = 0.021 G1/G2: P = 0.545 Receptive syntax: G1: NR^*^ G2: NR^*^ G1/BL: P = NS G2/BL: P = NS G1/G2: P = NS Expressive syntax: G1: NR^*^ G2: NR^*^ G1/BL: P = NS G2/BL: P = NS G1/G2: P = NS Phonology: G1: NR^*^ G2: NR^*^ G1/BL: P = NS G2/BL: P = NS G1/G2: P = NS Pragmatics: G1: NR^*^ G2: NR^*^ G1/BL: P = NS G2/BL: P = NS G1/G2: P = NS Harms: NR
| | | | Modifiers: NR

Comments:

* Data for nonsignificant results was not reported.

Aman et al., 2005

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Aman et al., 2005 McDougle et al., 2005^ Arnold et al., 2003† RUPP, 2002‡ Williams et al, 2006º Anderson et al., 2007^a^ Aman et al., 2008§ Martin et al., 2004¥ Country: US Practice setting: Academic centers Intervention setting: Clinic Enrollment period: June 1999 to April 2001 Funding: NIH; Kor-czak Foundation; Janssen (provided study medication) Author industry relationship disclosures: NR^‡^a^¥ 1 of 15† Lilly (1) McNeil (1) Novartis (1) Noven (1) Shire (1) Sigma Tau (1) 8 of 17º Abbott (2) AGS Publishing (2 VABS royalties) AstraZenca (1) Bristol-Myers Squibb (3) Cephalon (1) Forest (1) Jannssen (5) Lilly (5) McNeil (2) Novartis (1) Noven (1) Pediamed (1) Pfizer (4) Shire (2) Sigma Tau (1) Targacept (1) Wyeth (1) 7 of 17§ Bristol-Myers Squibb (6) Forest (3) Jannssen (4) Johnson and Johnson (1) Lilly (4) McNeil (3) Neuropharm (3) Novartis (2) Organon (1) Pfizer (1) Shire (3) Supernus (2) UCB (1) Wyeth (1) Design: Randomized trial with open label continuation phase | RCT intervention (8 weeks): Risperidone or placebo Dosage by weight:; - 20–45 kg: Initial dose of 0.5 mg at bedtime; increased to 0.5 mg twice daily on day 4; gradually increased in 0.5 mg increments to a maximum of 2.5 mg/day (1.0 mg AM, 1.5 mg bedtime) by day 29; - > 45 kg: slightly acelerated dose schedule, with maximal dose of 1.5 mg AM and 2.0 mg bedtime; - < 20 kg: initial dose 0.25 mg/day; Scheduled dose increase could be delayed due to AEs or marked improvement at lower dose; dose reductions to manage side effects allowed at any time; no dose increases after day 29 Daily dose during final study week, mean mg (range): G1: 1.8 ± 0.7 (0.5–3.5) G2: 2.4 ± 0.6 (1.0–3.5) Open label extension trial (8 weeks): The 46 RCT placebo nonresponders underwent an open label trial of risperidone after the RCT, with the same dosage schedule as the RCT Assessments: Lab tests, ECGS, prolactin and VABS maladaptive behavior pre- and post-RCT and post-extension Vital signs, height, weight, side effects, sleep log, SARS, AIMS at each visit | Inclusion criteria:; - Children meeting DSM-IV criteria for autistic disorder, with tantrums, aggression, self-injurious behavior, or a combination of these problems; - Aged 5 to 17 years; - Weight ≥ 15 kg; - Mental age ≥ 18 months; - Clinically significant behavioral problems with clinician-determined rating of ≥ moderate on CGI-S and score ≥ 18 on ABC Irritability subscale rated by parent and confirmed by caregiver (children reassessed at baseline, 7–14 days after initial assessment to confirm first values); Exclusion criteria:; - Serious medical disorders; - Other psychiatric disorders requiring medication; - Children receiving a psychotropic drug that was deemed effective for the treatment of aggression, tantrums, or self-injurious behavior; Age, RCT population, years (range): 8.8 ± 2.7 (5–17) Prepubertal, RCT population, n (%): 88 (87) Mental age: Mental development, RCT population, n (%): Average or above average IQ: G1: 3/46 (7) G2: 2/45 (4) Borderline IQ: G1: 8/46 (17) G2: 4/45 (9) Mild or moderate retardation: G1: 20/46 (43) G2: 23/45 (51) | Overall ratings: RLRS score, mean ± SD:^ Overall: G1: 0.94 ± 0.36 G2: 1.03 ± 0.37 Affectual reactions: G1: 1.68 ± 0.64 G2: 1.84 ± 0.64 Social skills: RLRS social relationship to people score, mean ± SD:^ G1: 0.60 ± 0.43 G2: 0.72 ± 0.43 VABS socialization score, mean ± SD:‡ G1: 49.1 ± 16.6 G2: 47.4 ± 10.1 Communication/language: RLRS language score, mean ± SD:^ G1: 0.28 ± 0.38 G2: 0.46 ± 0.42 VABS communication score, mean ± SD:‡ G1: 45.0 ± 16.7 G2: 42.0 ± 14.3 Repetitive behavior: ABC stereotypy score, mean ± SD:‡ G1: 10.6 ± 4.9 G2: 9.0 ± 4.4 Problem behavior: ABC score, mean ± SD:‡ Irritability: G1: 26.2 ± 7.9 G2: 25.5 ± 6.6 Social withdrawal: G1: 16.4 ± 8.2 G2: 16.1 ± 8.7 Hyperactivity: G1: 31.8 ± 9.6 G2: 32.3 ± 8.5 | Overall ratings: Rate of positive response (≥ 25% improvement on ABC irritability subscale and rating of much improved or very much improved on CGI-I scale), post-RCT, n (%):‡ G1: 34 (69)^**^ G2: 6 (12) G1/G2: P < 0.001 Rate of positive response, 8 week open label trial, n (%):^ G1: 29/46 (63) RLRS overall score, mean ± SD:^ Post-RCT: G1: 0.45 ± 0.31 G2: 0.88 ± 0.40 G1/G2: P < 0.001 (ES = 1.08) Post-extension phase: G1: 0.39 ± 0.35 RLRS affectual reactions score, mean ± SD:^ Post-RCT: G1: 0.88 ± 0.56 G2: 1.60 ± 0.71 G1/G2: P < 0.001 (ES = 1.10) Post-extension phase: G1: 0.78 ± 0.58 Social skills: RLRS social relationship to people score, mean ± SD:^ Post-RCT: G1: 0.15 ± 0.42 G2: 0.46 ± 0.52 G1/G2: P = NS (ES = 0.68)
| RLRS at pre-, mid- and post-RCT, monthly thereafter CYBOCS, CGI and ABC bi-weekly during RCT and monthly thereafter Target symptoms, California VLT, Dot Test, Cancellation and Purdue Peg Board tasks pre-, mid-and post-RCT VABS at pre-RCT and post-extension Groups: G1: risperidone G2: placebo Co-interventions held stable during treatment: NR Frequency of contact during study: Weekly during RCT, monthly thereafter Concomitant therapies: NR N at RCT enrollment: G1: 49 G2: 52 N at start of 8 week extension trial: G1: 46 | Severe retardation: G1: 15/46 (33) G2: 16/45 (36) Gender, RCT population, n (%): Male: G1: 39 (80) G2: 43 (52) Female: G1: 10 (20) G2: 9 (17) Race/ethnicity, RCT population, n (%): White: 67 (66) Black: 11 (11) Hispanic: 7 (7) Asian: 8 (8) Other: 8 (8) SES: Education of parent or primary caregiver, n (%): High school or less: G1: 9 (18) G2: 13 (25) Trade school or college: G1: 33 (67) G2: 31 (60) Advanced degree: G1: 7 (14) G2: 8 (15) Annual household income, n (%): < $20,000: G1: 5/48 (10) G2: 8/51 (16) $20,001–$40,000: G1: 12/48 (25) G2: 16/51 (31) $40,001–$60,000: G1: 10/48 (21) G2: 7/51 (15) > $60,000: G1: 21/48 (44) G2: 20/51 (39) Diagnostic approach: In Study Diagnostic tool/method: Diagnosis corroborated by ADI-R, administered by a clinician with special training and systematic review to ensure reliability | Inappropriate speech: G1: 4.8 ± 4.1 G2: 6.5 ± 3.6 VABS maladaptive behavior score, mean ± SD:^ Part 1: G1: 24.89 ± 6.91 G2: 25.22 ± 5.72 Part 2: G1: 8.37 ± 2.59 G2: 8.29 ± 3.66 Total: G1: 33.26 ± 8.38 G2: 33.51 ± 8.29 Adaptive behavior: VABS score, mean ± SD:‡ Daily living: G1: 40.8 ± 21.0 G2: 34.0 ± 15.6 Medical: CYBOCS score, mean ± SD:^ G1: 15.51 ± 2.73 G2: 15.18 ± 3.88 BMI, CDC standard score, mean ± SD: G1: 0.4 ± 1.4 G2: 0.7 ± 1.3 SARS score, mean ± SD: G1: 0.27 ± 0.70 G2: 0.54 ± 1.60 AIMS score, mean ± SD: G1: 0.36 ± 0.99 G2: 0.23 ± 1.02 Sleep time, mean hours/day: G1: 9.66 G2: 9.42 Serum prolactin, mean ng/mL ± SD:^a^ G1: 9.3 ± 7.5 (n=42) G2: 9.3 ± 7.6 (n=36) Motor skills: Purdue pegboard, mean ± SD:§ | Post-extension phase: G1: 0.00 ± 0.42 VABS socialization, standard score, postextension phase, mean change ± SD:º G1: 1.83 ± 9.64 (n=48) G1/BL: P = NS (ES = 0.14) Communication/language: RLRS language score, mean ± SD:^ Post-RCT: G1: 0.03 ± 0.29 G2: 0.34 ± 0.41 G1/G2: P = NS (ES = 0.81) Post-extension phase: G1: 0.10 ± 0.36 VABS communication, standard score, postextension phase, mean change ± SD:º G1: 1.63 ± 8.91 (n=48) G1/BL: P = NS (ES = 0.11) Repetitive behavior: ABC stereotypy score, mean ± SD: Post-RCT:‡ G1: 5.8 ± 4.6 G2: 7.3 ± 4.8 G1/G2: P < 0.001 (ES = 0.8) (ES = 1.2)
| | Diagnostic category: See inclusion criteria CGI-S, RCT population, n (%) Moderate: G1: 9/49 (18) G2: 9/49 (18) Marked: G1: 27/49 (55) G2: 28/49 (57) Severe: G1: 12/49 (24) G2: 12/49 (24) Extreme: G1: 1/49 (2) G2: 0 Other characteristics, n (%): Educational placement of child, RCT population: Regular class: G1: 5/47 (11) G2: 3/50 (6) Special education program: G1: 42/47 (89) G2: 46/50 (92) Residential school: G1: 0 G2: 1/50 (2) Current anticonvulsant treatment, RCT population: G1: 2/49 (4) G2: 2/49 (4) Previous medication, RCT population: None: G1: 8/41 (20) G2: 10/35 (29) Antipsychotic agent: G1: 4/41 (10) G2: 1/35 (3) SSRI: G1: 6/41 (15) G2: 10/35 (29) Stimulant: G1: 14/41 (34) G2: 7/35 (20) Alpha-2 adrenergic agonist: G1: 9/41 (22) G2: 7/35 (20) Child living at home with at least 1 parent, RCT population: 92 (91) | Dominant hand insert: G1: 32.76 ± 17.4 (n=17) G2: 24.08 ± 10.5 (n=13) Nondominant hand insert: G1: 26.82 ± 18.4 (n=17) G2: 22.38 ± 9.9 (n=13) Dominant hand drops: G1: 2.35 ± 1.9 (n=17) G2: 2.77 ± 2.4 (n=13) Nondominant hand drops: G1: 3.24 ± 3.0 (n=17) G2: 2.31 ± 2.4 (n=13) Both hands inserts: G1: 59.59 ± 35.3 (n=17) G2: 46.46 ± 19.5 (n=13) Both hands drops: G1: 5.59 ± 4.0 (n=17) G2: 5.08 ± 4.3 (n=13) Sensory: RLRS score, mean ± SD:^ Sensory motor behaviors: G1: 1.00 ± 0.52 G2: 0.93 ± 0.58 Sensory responses: G1: 1.13 ± 0.53 G2: 1.21 ± 0.53 | Problem behavior: ABC irritability score, post-RCT, mean ± SD:‡ G1: 11.3 ± 7.4 G2: 21.9 ± 9.5 G1/G2: P < 0.001 ABC lethargy/social withdrawal score, mean ± SD: Post-RCT:‡ G1: 8.9 ± 6.4 G2: 12.0 ± 8.3 G1/G2: P = 0.03 (ES = 0.4) ABC hyperactivity score, mean ± SD: Post-RCT:‡ G1: 17.0 ± 9.7 G2: 27.6 ± 10.6 G1/G2: P < 0.001 (ES = 1.0) ABC inappropriate speech score, mean ± SD: Post-RCT:‡ G1: 3.0 ± 3.1 G2: 5.9 ± 3.8 G1/G2: P = 0.03 (ES = 0.3) VABS maladaptive behavior score, part 1, mean ± SD:^ Post-RCT: G1: 14.89 ± 5.93 G2: 22.97 ± 5.99 G1/G2: P < 0.001 (ES = 1.17) Post-extension phase: G1: 16.55 ± 6.87 VABS maladaptive behavior score, part 2, mean ± SD:^ Post-RCT: G1: 5.45 ± 3.25 G2: 7.30 ± 3.45 G1/G2: P = 0.02 (ES = 0.49)
| | | Educational/cognitive/academic attainment: Cancellation task, mean ± SD:§ Correct detections: G1: 126.75 ± 46.9 (n=12) G2: 110.71 ± 56.3 (n=7) Commissions: G1: 6.50 ± 22.2 (n=12) G2: 2.29 ± 4.3 (n=7) Omissions: G1: 11.75 ± 22.6 (n=12) G2: 19.00 ± 20.3 (n=7) Analogue classroom task, mean ± SD:§ Number attempted: G1: 22.88 ± 14.7 (n=8) G2: 31.63 ± 11.0 (n=8) Number correct: G1: 19.25 ± 11.4 (n=8) G2: 24.50 ± 10.5 (n=8) Verbal learning task, mean ± SD:§ Immediate recall: G1: 28.50 ± 11.9 (n=12) G2: 25.00 ± 8.8 (n=8) Delayed recall: G1: 6.20 ± 4.6 (n=12) G2: 4.67 ± 2.9 (n=8) Recognition: G1: 77.87 ± 19.1 (n=12) G2: 81.00 ± 11.6 (n=8) | Post-extension phase: G1: 5.04 ± 3.20 VABS maladaptive behavior total score, mean ± SD:^ Post-RCT: G1: 20.34 ± 7.93 G2: 30.27 ± 8.87 G1/G2: P < 0.001 (ES = 1.03) Post-extension phase: G1: 21.60 ± 9.50 Target symptom ratings (lower scores better) post-RCT, mean ± SD:† G1: 2.8 ± 1.16 (n=44) G2: 4.5 ± 1.28 (n=43) G1/G2: P < 0.001 (ES = 1.39) Adaptive behavior: VABS standard score, postextension phase, mean change ± SD:º Composite: G1: − 0.29 ± 12.53 (n=48) G1/BL: P = NS (ES = −0.02) Daily living skills: G1: 0.96 ± 10.35 (n=48) G1/BL: P = NS (ES = 0.06) Medical: CYBOCS score, post-RCT, mean ± SD:^ G1: 11.65 ± 4.02 G2: 14.21 ± 4.81 G1/G2: P = 0.005 (ES = 0.55)
| | | Dot test, mean ± SD:§ Average distance: G1: 2.40 ± 1.0 (n=4) G2: 3.52 ± 1.8 (n=4) Average distancedelay: G1: 7.19 ± 2.34 (n=4) G2: 4.95 ± 2.2 (n=4) Difference: G1: 4.79 ± 2.0 (n=4) G2: 1.43 ± 1.5 (n=4) Harms: Potential harms, %: Difficulty falling asleep: G1: 32.7 G2: 50.0 Tired during day: G1: 14.3 G2: 23.1 Enuresis: G1: 40.8 G2: 32.7 Anxiety: G1: 20.4 G2: 32.7 Rhinitis: G1: 12.2 G2: 17.3 Excessive appetite: G1: 12.2 G2: 11.5 Coughing: G1: 8.2 G2: 19.2 Dry mouth: G1: 12.2 G2: 11.5 Nausea/vomiting: G1: 4.1 G2: 5.8 Diarrhea: G1: 8.2 G2: 9.6 Difficulty waking: G1: 14.3 G2: 19.2 | Weight increase, post-RCT, mean kg ± SD:‡ G1: 2.7 ± 2.9 G2: 0.8 ± 2.2 G1/G2: P < 0.001 Weight increase, extension phase, mean kg ± SD (range):¥ G1: 5.6 ± 3.9 (−4.0 −15.3) BMI, CDC standard score, post-RCT, mean ± SD: G1: 1.0 ± 1.2 G2: 0.8 ± 1.3 G1/G2: P < 0.001 BMI increase, extension phase, mean kg/m^2^ ± SD:¥ G1: 2.0 ± 1.9 SARS score, post-RCT, mean ± SD: G1: 0.52 ± 1.33 G2: 0.69 ± 2.48 G1/G2: P = NS SARS score, maximum value during extension ± SD: G1: 0.71 ± 2.67 AIMS score, post-RCT, mean ± SD: G1: 0.17 ± 0.57 G2: 0.22 ± 0.73 G1/G2: P = NS AIMS score, maximum values during extension ± SD: G1: 0.11 ± 0.50 Sleep time, mean hours/day, RCT phase: G1: 10.33 G2: 9.70 G1/G2: P = NS
| | | Constipation: G1: 16.3 G2: 11.5 Skin rash: G1: 8.2 G2: 7.7 Headaches: G1: 10.2 G2: 5.8 Dyspepsia: G1: 0 G2: 1.9 Excessive saliva: G1: 4.1 G2: 7.7 Dizziness/loss of balance: G1: 0 G2: 1.9 Tachycardia: G1: 2.0 G2: 1.9 Muscles appear stuck: G1: 0 G2: 5.8 Tongue movements: G1: 4.1 G2: 3.8 | Serum prolactin, post-RCT, mean ng/mL ± SD:^a^ G1: 39.0 ± 19.2 G2: 10.1 ± 8.8 G1/G2: P < 0.0001 Serum prolactin, 6 months, mean ng/mL ± SD:^a^ G1: 32.4 ± 17.8 (n=43) G1/BL: P < 0.0001 G1/PE: P = 0.009 Serum prolactin, 22 ± 2 months, mean ng/mL ± SD:^a^ G1: 25.3 ± 15.6 (n=30) G1/BL: P < 0.0001 Motor skills: Purdue pegboard, post-RCT, mean ± SD:§ Dominant hand insert: G1: 34.59 ± 16.0 (n=17) G2: 28.38 ± 13.9 (n=13) ANOVA: time (P ≤ 0.05) Nondominant hand insert: G1: 29.53 ± 14.7 (n=17) G2: 24.23 ± 10.3 (n=13) Dominant hand drops: G1: 4.00 ± 3.4 (n=17) G2: 3.00 ± 2.6 (n=13)
| | | | Nondominant hand drops: G1: 4.00 ± 3.00 (n=17) G2: 3.54 ± 2.9 (n=13) Both hands inserts: G1: 64.12 ± 30.0 (n=17) G2: 52.62 ± 23.2 (n=13) Both hands drops: G1: 8.00 ± 5.5 (n=17) G2: 6.54 ± 4.9 (n=13) Sensory: RLRS-sensory motor behaviors mean ± SD:^ Post-RCT: G1: 0.59 ± 0.42 G2: 0.91 ± 0.60 G1/G2: P = 0.002 (ES = 0.45) Post-extension phase: G1: 0.60 ± 0.49 RLRS sensory responses score, mean ± SD:^ Post-RCT: G1: 0.60 ± 0.38 G2: 1.07 ± 0.54 G1/G2: P = 0.004 (ES = 0.77) Post-extension phase: G1: 0.45 ± 0.37
| | | | Educational/cognitive/academic attainment: Cancellation task, post-RCT, mean ± SD:§ Correct detections: G1: 138.50 ± 59.7 (n=12) G2: 95.29 ± 59.7 (n=7) ANOVA: drug × time (P ≤ 0.05) Commissions: G1: 0.08 ± 0.3 (n=12) G2: 4.09 ± 9.7 (n=7) Omissions: G1: 10.00 ± 19.3 (n=12) G2: 27.75 ± 33.8 (n=7) Analogue classroom task, post-RCT, mean ± SD:§ Number attempted: G1: 24.50 ± 5.8 (n=8) G2: 32.50 ± 15.7 (n=8) Number correct: G1: 20.50 ± 6.6 (n=8) G2: 26.63 ± 18.0 (n=8)
| | | | Verbal learning task, post-RCT, mean ± SD:§ Immediate recall: G1: 31.92 ± 11.6 (n=12) G2: 29.88 ± 8.9 (n=8) ANOVA: time (P ≤ 0.01) Delayed recall: G1: 7.40 ± 2.7 (n=12) G2: 4.83 ± 2.9 (n=8) Recognition: G1: 83.17 ± 15.4 (n=12) G2: 81.00 ± 11.6 (n=8) ANOVA: drug × time (P ≤ 0.05) Dot test, post-RCT, mean ± SD:§ Average distance: G1: 2.57 ± 1.3 (n=4) G2: 2.90 ± 1.3 (n=4) Average distancedelay: G1: 5.08 ± 2.4 (n=4) G2: 5.27 ± 2.6 (n=4) Difference: G1: 2.52 ± 2.0 (n=4) G2: 2.38 ± 2.9 (n=4) ANOVA: drug × time (P ≤ 0.05) Harms: AEs during RCT, n (%):‡ Mild increased appetite: G1: 24/49 (49) G2: 13/51 (25) G1/G2: P = 0.03
| | | | Moderate increased appetite: G1: 12/49 (24) G2: 2/51 (4) G1/G2: P = 0.01 Nasal congestion: G1: 25/49 (51) G2: 20/51 (39) G1/G2: P = 0.32 Fatigue: G1: 29/49 (59) G2: 14/51 (27) G1/G2: P = 0.003 Enuresis: G1: 15/49 (31) G2: 15/51 (29) G1/G2: P = 0.93 Drowsiness: G1: 24/49 (49) G2: 6/51 (12) G1/G2: P < 0.001 Vomiting: G1: 16/49 (33) G2: 12/51 (24) G1/G2: P = 0.24 Insomnia: G1: 7/49 (14) G2: 15/51 (29) G1/G2: P = 0.11 Anxiety: G1: 12/49 (24) G2: 10/51 (20) G1/G2: P = 0.73 Diarrhea: G1: 9/49 (18) G2: 11/51 (22) G1/G2: P = 0.88 Constipation: G1: 14/49 (29) G2: 6/51 (12) G1/G2: P = 0.06 Sleep problems: G1: 11/49 (22) G2: 9/51 (18) G1/G2: P = 0.73 Skin irritation: G1: 11/49 (22) G2: 7/51 (14) G1/G2: P = 0.38
| | | | Drooling: G1: 13/49 (27) G2: 3/51 (6) G1/G2: P = 0.02 Headache: G1: 9/49 (18) G2: 6/51 (12) G1/G2: P = 0.52 Stomachache: G1: 5/49 (10) G2: 9/51 (18) G1/G2: P = 0.43 Dry mouth: G1: 9/49 (18) G2: 5/51 (10) G1/G2: P = 0.34 Increased thirst: G1: 6/49 (12) G2: 5/51 (10) G1/G2: P = 0.94 Dizziness: G1: 8/49 (16) G2: 2/51 (4) G1/G2: P = 0.05 Dyskinesia: G1: 6/49 (12) G2: 3/51 (6) Nausea: G1: 4/49 (8) G2: 5/51 (10) G1/G2: P = 0.95 Decreased appetite: G1: 3/49 (6) G2: 5/51 (10) G1/G2: P = 0.76 Tremor: G1: 7/49 (14) G2: 1/51 (2) G1/G2: P = 0.06 Tachycardia: G1: 6/49 (12) G2: 1/51 (2) G1/G2: P = 0.06 Upper respiratory tract infection: G1: 5/49 (10) G2: 2/51 (4) G1/G2: P = 0.40
| | | | Earache: G1: 2/49 (4) G2: 4/51 (8) G1/G2: P = 0.71 Muscle rigidity: G1: 5/49 (10) G2: 1/51 (2) Sore throat: G1: 5/49 (10) G2: 1/51 (2) G1/G2: P = 0.11 Restlessness: G1: 3/49 (6) G2: 3/51 (6) G1/G2: P = 0.71 Elevated serum glutamicoxaloacetic transaminase level: G1: 1 G2: 1 Elevated serum glutamic-pyruvic transaminase level: G1: 0 G2: 1 Nonspecific, clinically insignificant changes in cardiac conduction: G1: 0 G2: 1 Fever in association with documented time-limited illness, n: G1: 8 G2: 10 Withdrew due to AEs, RCT study: G1: 0 G2: 0
| | | | AEs during RCT, % (overall symptom P-values): Difficulty falling asleep: Mild: G1: 24.5 G2: 30.8 Moderate/severe: G1: 22.4 G2: 34.6 G1/G2: P = 0.02 Tired during day Mild: G1: 57.1 G2: 42.3 Moderate/severe: G1: 36.8 G2: 11.5 G1/G2: P < 0.0001 Enuresis: Mild: G1: 32.7 G2: 19.2 Moderate/severe: G1: 32.7 G2: 28.8 G1/G2: P = 0.11 Anxiety: Mild: G1: 18.1 G2: 14.2 Moderate/severe: G1: 32.7 G2: 15.4 G1/G2: P = 0.05 Rhinitis: Mild: G1: 38.8 G2: 36.5 Moderate/severe: G1: 16.3 G2: 7.7 G1/G2: P = NS Excessive appetite: Mild: G1: 49.0 G2: 28.8
| | | | Moderate/severe: G1: 32.6 G2: 9.6 G1/G2: P < 0.0001 Coughing: Mild: G1: 40.8 G2: 21.2 Moderate/severe: G1: 6.1 G2: 15.4 G1/G2: P = NS Dry mouth: Mild: G1: 40.8 G2: 26.9 Moderate/severe: G1: 2.0 G2: 1.9 G1/G2: P = 0.15 Nausea/vomiting: Mild: G1: 36.7 G2: 23.1 Moderate/severe: G1: 4.0 G2: 5.8 G1/G2: P = 0.20 Diarrhea: Mild: G1: 26.5 G2: 19.2 Moderate/severe: G1: 4.1 G2: 9.6 G1/G2: P = NS Difficulty waking: Mild: G1: 34.7 G2: 19.2 Moderate/severe: G1: 12.2 G2: 7.7 G1/G2: P = 0.05 Constipation: Mild: G1: 28.6 G2: 13.5 Moderate/severe: G1: 10.2 G2: 11.5 G1/G2: P = 0.14
| | | | Skin rash: Mild: G1: 24.5 G2: 15.4 Moderate/severe: G1: 2.0 G2: 1.9 G1/G2: P = NS Headaches: Mild: G1: 18.4 G2: 11.5 Moderate/severe: G1: 4.1 G2: 5.8 G1/G2: P = NS Dyspepsia: Mild: G1: 10.2 G2: 11.5 Moderate/severe: G1: 0 G2: 5.8 G1/G2: P = 0.19 Excessive saliva: Mild: G1: 24.5 G2: 9.6 Moderate/severe: G1: 4.0 G2: 1.9 G1/G2: P = 0.04 Dizziness/loss of balance: Mild: G1: 16.3 G2: 7.7 Moderate/severe: G1: 6.1 G2: 0 G1/G2: P = 0.04 Tachycardia: Mild: G1: 6.1 G2: 7.7 Moderate/severe: G1: 2.0 G2: 0 G1/G2: P = NS
| | | | Muscles appear stuck: Mild: G1: 4.1 G2: 3.8 Moderate/severe: G1: 4.1 G2: 1.9 G1/G2: P = NS Tongue movements: Mild: G1: 6.1 G2: 3.8 Moderate/severe: G1: 4.0 G2: 0 G1/G2: P = NS AEs, 8 week open label trial, %: Difficulty falling asleep: Mild: G1: 54.1 Moderate/severe: G1: 10.8 Tired during day Mild: G1: 83.8 Moderate/severe: G1: 2.7 Enuresis: Mild: G1: 43.2 Anxiety: Mild: G1: 35.1 Moderate/severe: G1: 2.7 Rhinitis: Mild: G1: 45.9 Excessive appetite: Mild: G1: 73.0 Coughing: Mild: G1: 35.1 Dry mouth: Mild: G1: 37.8
| | | | Nausea/vomiting: Mild: G1: 27.0 Diarrhea: Mild: G1: 32.4 Difficulty waking: Mild: G1: 54.1 Moderate/severe: G1: 10.8 Constipation: Mild: G1: 18.9 Moderate/severe: G1: 2.7 Skin rash: Mild: G1: 18.9 Headaches: Mild: G1: 13.5 Moderate/severe: G1: 2.7 Dyspepsia: Mild: G1: 8.1 Excessive saliva: Mild: G1: 35.1 Dizziness/loss of balance: Mild: G1: 13.5 Moderate/severe: G1: 2.7 Tachycardia: Mild: G1: 10.8 Muscles appear stuck: Mild: G1: 5.4 Moderate/severe: G1: 2.7 Tongue movements: Mild: G1: 2.7
| | | | AEs, pre-extension phase, %: Excessive appetite: G1: 54.0 Enuresis: G1: 41.3 Tired during day: G1: 22.2 Dry mouth: G1: 20.6 Coughing: G1: 19.0 Anxiety: G1: 19.0 Rhinitis: G1: 15.9 Excess saliva: G1: 12.7 Nausea/vomiting: G1: 6.3 Difficulty falling asleep: G1: 6.3 Gynecomastia: G1: 3.2 Difficulty waking: G1: 4.8 Diarrhea: G1: 6.3 Constipation: G1: 6.3 Skin rash: G1: 1.6 Muscles “stuck”: G1: 3.2 AEs, extension phase, month 4, %: Excessive appetite: G1: 49.1 Enuresis: G1: 35.1 Tired during day: G1: 21.1
| | | | Dry mouth: G1: 15.8 Coughing: G1: 12.3 Anxiety: G1: 14.0 Rhinitis: G1: 15.8 Excess saliva: G1: 15.8 Nausea/vomiting: G1: 10.5 Difficulty falling asleep: G1: 10.5 Gynecomastia: G1: 7.0 Difficulty waking: G1: 5.3 Diarrhea: G1: 3.5 Constipation: G1: 3.5 Skin rash: G1: 8.8 Muscles “stuck”: G1: 3.5 Withdrew due to AEs, extension phase: G1: 1 (constipation) Modifiers: No clinical complaints or physical findings associated with changes in prolactin; no significant effects of DRD2 polymorphisms on changes in serum prolactin from baseline to end of RCT^a^

Comments:

* 30 from the RCT risperidone group, 30 from the placebo non-responders, and 3 who did not meet open label response criteria but were still included in phase.

** Gains in risperidone group maintained for 6 month extension phase in 23 of 34 children (68%) with positive responses during RCT. Of the other 11 responders, 4 did not enter extension phase. 2 children’s parents decided to seek other treatment in addition to risperidone, 4 were withdrawn because treatment was no longer effective, and 1 was withdrawn due to an unrelated medical problem.‡

Anan et al., 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Anan et al., 2008 Country: US Practice setting: Private practice Intervention setting: Clinic and home Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: Prospective case series | Intervention: Group Intensive Family Training (GIFT); 12 hour didactic weekend followed by a 12 week (180 hour, 3 hours each weekday) of parent training in EIBI Groups: G1: intervention group Assessments: Prior to treatment, skill strengths and deficits were evaluated; informal preference assessments conducted to identify effective reinforcers for acquisition of new skills; problem behaviors MSEL, VABS Provider: Parents trained by a board-certified behavior analyst and 4 staff members with experience implementing behavior analytic training Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 81 N at follow-up: G1: 72 | Inclusion criteria:; - Children diagnosed with ASD using the DSM-IV criteria by experienced physicians and/or clinical psychologists in the community; - Significant impairment relative to chronological age (e.g., score on measures of cognitive and/or adaptive functioning more than 2 SD below the mean); Exclusion criteria:; - See inclusion criteria; Age, months ± SD (range): 44 ± 12.6 (25–68) Mental age: NR Gender, %: Male: 84.7 Female: 15.3 Race/ethnicity: NR SES: Parent/caregiver years of post-high school education, mean: 3 Household income: NR Diagnostic approach: Referral Diagnostic tool/method: DSMIV clinical interview Diagnostic category, n (%): Autism: 72 (100) Other characteristics: NR | Overall ratings: MSEL composite score, mean ± SD: G1: 51.69 ± 6.27 MSEL visual reception score, mean ± SD: G1: 60.10 ± 11.84 VABS composite score, mean ± SD: G1: 53.11 ± 7.39 Social skills: VABS socialization: score, mean ± SD: G1: 56.17 ± 5.29 Communication/language: MSEL receptive language score, mean ± SD: G1: 56.58 ± 5.62 MSEL expressive language score, mean ± SD: G1: 56.31 ± 5.24 VABS communication score, mean ± SD: G1: 54.61 ± 8.35 Adaptive behavior: VABS daily living skills score, mean ± SD: G1: 57.59 ± 7.96 Motor skills: MSEL fine motor score, mean ± SD: G1: 57.35 ± 7.59 VABS motor skills score, mean ± SD: G1: 62.74 ± 13.50 Educational/cognitive/academic attainment: MSEL developmental age, months ± SD: Composite: G1: 16.99 ± 5.64 | Overall ratings: MSEL composite score, mean ± SD: G1: 59.65 ± 16.58 G1/BL: P < 0.001 MSEL composite score ≥ 70, n (%): G1: 10 (14) MSEL visual reception score, mean ± SD: G1: 70.99 ± 23.00 G1/BL: P < 0.001 VABS composite score, mean ± SD: G1: 58.27 ± 9.59 G1/BL: P < 0.001 VABS composite score ≥ 70, n (%): G1: 8 (11) Social skills: VABS socialization: score, mean ± SD: G1: 61.54 ± 8.39 G1/BL: P < 0.001 Communication/language: MSEL receptive language score, mean ± SD: G1: 63.94 ± 20.86 G1/BL: P < 0.001 MSEL expressive language score, mean ± SD: G1: 63.81 ± 19.40 G1/BL: P < 0.001 VABS communication score, mean ± SD: G1: 60.09 ± 12.19 G1/BL: P < 0.001 Adaptive behavior: VABS daily living skills score, mean ± SD: G1: 59.70 ± 8.65 G1/BL: P < 0.01
| | | Visual reception: G1: 20.90 ± 6.52 Fine motor: G1: 21.44 ± 5.30 Receptive language: G1: 13.39 ± 7.17 Expressive language: G1: 12.21 ± 7.12 VABS developmental age, months ± SD: Composite: G1: 15.91 ± 3.60 Communication: G1: 11.90 ± 4.71 Socialization: G1: 10.30 ± 2.56 Daily living skills: G1: 17.86 ± 3.96 Motor skills: G1: 23.57 ± 6.20 | Motor skills: MSEL fine motor score, mean ± SD: G1: 65.29 ± 18.97 G1/BL: P < 0.001 VABS motor skills score, mean ± SD: G1: 70.06 ± 16.20 G1/BL: P < 0.001 Educational/cognitive/academic attainment: MSEL developmental age, months ± SD: Composite: G1: 25.20 ± 7.93 Visual reception: G1: 29.51 ± 7.61 Fine motor: G1: 28.46 ± 8.81 Receptive language: G1: 21.85 ± 10.22 Expressive language: G1: 21.00 ± 10.36 VABS developmental age, months ± SD: Composite: G1: 21.65 ± 5.71 Communication: G1: 17.87 ± 6.37 Socialization: G1: 15.75 ± 4.83 Daily living skills: G1: 21.68 ± 5.67 Motor skills: G1: 30.99 ± 9.41 Harms: NR Modifiers: NR

Andersen et al., 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Andersen et al., 2008 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: None Design: Retrospective case series | Intervention: Melatonin given 30 minutes to one hour before bedtime Children under 6 started on 0.75–1 mg and increased by 1 mg every 2 weeks up to 3 mg if no response at lower dose Children 6 and older started on 1.5 mg and increased to 3 mg after 2 weeks if no response All children who did not show a response after 4 weeks were increased to 6 mg Sleep hygiene techniques were suggested with start of melatonin Assessments: Parent report in medical chart; children were from a single pediatrician’s practice (specializing in ASD) Groups: G1: melatonin (dose range: 0.75–6.0 mg) Measure of treatment fidelity reported: Parental compliance with sleep hygiene techniques documented in 65 (58%) children Co-interventions held stable during treatment: NR Frequency of contact during study: 2–6 month intervals for an average of 1.8 ± 1.4 years after initiating melatonin (18 children had only 1 documented follow-up visit after initiation of melatonin) | Inclusion criteria:; - Clinical diagnosis of ASD based on DSM-IV criteria; - Confirmed use of supplemental melatonin for sleep concerns based on medication records at follow-up clinical visits; Exclusion criteria:; - Comorbid childhood bipolar disorder; Age, years (range): NR (2–18) Mental age: NR Gender, %: Male: 80 Female: 20 Race/ethnicity, %: Caucasian: 60 African American: 6 Race unknown: 34 SES: Maternal education: NR Household income: NR Diagnostic approach: NR Diagnostic tool/method: Chart review, based on DSM-IV criteria Diagnostic category, %: Autistic disorder: 71 PDD-NOS: 19 Aspergers: 5 Other characteristics, n (%): Epileptic seizures: 21 (20) Refractory epilepsy: 4 (4) Comorbid psychiatric diagnoses, including ADHD, OCD, depression, ODD, anxiety: 31 (29) Mean age at onset of sleep problems, years ± SD: 6.7 ± 3.8 Mean age at start of melatonin, years ± SD: 8 ± 3.9 | Overall ratings: Sleep complaints, %: Sleep-onset insomnia only: 23 Sleep-maintenance insomnia only: 8 Both sleep-onset and sleepmaintenance insomnia: 68 Early awakening: 1 Medication-free at baseline, n (%):^*^ 45 (42) | Overall ratings: Quality of sleep, n (%): No longer reported sleep concerns: 27 (25) Improved sleep, but still some concerns in follow-up visits: 64 (60)^**^ Sleep still a major concern: 14 (13) Worse sleep after melatonin: 1 (1) Undetermined response: 1 (1) Harms: Morning sleepiness, fogginess, increased enuresis, n: 3 Modifiers: No significant difference in melatonin response between medication-free before taking melatonin vs. prescribed psychotropic medication.
| Concomitant therapies, n (%): Any psychotropic medication use: 96 (90) Antidepressants: 60 (56) Antipsychotics: 68 (64) Sedative/hypnotics: 50 (45) Antiepileptics: 36 (34) Stimulants: 46 (43) N at enrollment: G1: 107 N at follow-up: G1: 107

Comments:

* 34 of these 45 children started psychotropic medication within 2–6 months after initiation of melatonin.

** 7 initially reported improvement, but sleep problems returned after 3–12 months

Beaumont et al., 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Beaumont et al., 2008 Country: Australia Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: 1 of 2 The Junior Detective Training Program (future royalties) Design: RCT | Intervention: The Junior Detective Training Program: group social skills training, parent training, teacher handouts and a computer game 2 hour training sessions for 7 consecutive weeks:; - Sessions 1 & 2: 1 hour training, 1 hour group therapy and parent training; - Sessions 3 & 4: 45 min training, 75 min group therapy and parent training; - Sessions 5 & 6: little group therapy and parent training; - Session 7: 1 hour group therapy, 1 hour reassessment; Provider:; - Chief investigator; - Two intern therapists enrolled in postgraduate clinical psychology and counseling degrees; Assessments: Developmental history questionnaire; CAST; SSQ parent and teacher forms; ERSSQ; WISC-III short-form; Assessment of Perception of Emotion from Facial Expression (Spence, 1995b); Assessment of Perception of Emotion from Posture Cues (Spence, 1995c); James and the Maths Test (Attwood, 2004a); Dylan is Being Teased (Attwood, 2004b) Groups: G1: new treatment G2: wait-list Measure of treatment fidelity reported: Yes | Inclusion criteria:; - AS diagnosis confirmed by pediatrician; - WISC-III pro-rated IQ score of ≥ 85; - Age 7.5–11 years at intake; Exclusion criteria:; - See inclusion criteria; Age: years ± SD (range): G1: 9.64 ± 1.21 (7.5–11.7) G2: 9.81 ± 1.26 (8.1–11.7) Mental age: WISC-III IQ, mean ± SD (range): G1: 107.15 ± 11.94 (85–130) G2: 107.43 ± 14.21 (85–138) Gender, n: Male: G1: 23 G2: 21 Female: G1: 3 G2: 2 Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: AS diagnosis confirmed by pediatrician; parents completed questionnaire including diagnostic items and CAST Diagnostic category, n (%): Asperger Syndrome: 49 (100) Other characteristics: CAST score, mean ± SD (range): G1: 21.63 ± 3.51 (17–29) G2: 21.61 ± 2.78 (17–26) | Social Skills: SSQ score, parent rated, mean ± SD (range): G1: 25.30 ± 7.43 (12–41) G2: 23.16 ± 9.05 (7–44) SSQ score, parent rated, follow-up group, mean ± SD (range): G1: 25.30 ± 7.43 (12–41) G2: 25.09 ± 7.34 (7–42)^*^ ERSSQ score, mean ± SD (range): G1: 39.78 ± 10.17 (23–64) G2: 39.64 ± 12.52 (17–64) ERSSQ score, follow-up group, mean ± SD (range): G1: 39.78 ± 10.17 (23–64) G2: 39.96 ± 10.27 (12–64)^*^ Emotion Recognition: Assessment of Perception of Emotion score, mean ± SD (range): Facial expression: G1: 17.44 ± 2.67 (12–24) G2: 18.30 ± 2.46 (13–22) Body posture: G1: 20.48 ± 3.15 (14–24) G2: 20.96 ± 2.44 (16–24) | Social skills: SSQ score, parent rated, mean ± SD (range): G1: 38.08 ± 9.84 (15–55) G2: 25.11 ± 7.91 (7–42) G1/BL: P < 0.001 G2/BL: P = NS G1/G2: P < 0.05 SSQ score, parent rated, follow-up group, mean ± SD (range): Post-treatment: G1: 38.08 ± 9.84 (15–55) G2: 41.50 ± 8.55 (29–58)^*^ G1/BL: P < 0.001 G2/BL: P < 0.001 6 weeks: G1: 43.24 ± 8.81 (24–58) G2: 39.96 ± 9.46 (22–59)^*^ G1/BL: P < 0.001 G2/BL: P < 0.001 5 months: G1: 40.64 ± 12.85 (13–60) G2: 41.17 ± 8.48 (28–58)^*^ G1/BL: P < 0.001 G2/BL: P < 0.001 ERSSQ score, mean ± SD (range): G1: 57.38 ± 13.40 (32–80) G2: 40.14 ± 10.69 (12–64) G1/BL: P < 0.001 G2/BL: P = NS G1/G2: P < 0.05
| Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 26 G2: 23 N at follow-up: G1: 25 G2: 21 | | Assessment of Perception of Emotion score, follow-up group, mean ± SD (range): Facial expression: G1: 17.40 ± 2.75 (12–24) G2: 19.35 ± 2.82 (15–24)^*^ Body posture: G1: 20.44 ± 3.16 (14–24) G2: 20.96 ± 2.44 (16–24)^*^ Emotion Management: Dylan is Being Teased score, mean ± SD (range): G1: 2.93 ± 1.62 (0–6) G2: 2.78 ± 1.59 (0–6) Dylan is Being Teased score, follow-up group, mean ± SD (range): G1: 3.00 ± 1.55 (0–6) G2: 2.39 ± 1.67 (0–6)^*^ James and the Maths Test score, mean ± SD (range): G1: 1.70 ± 1.07 (0–4) G2: 1.74 ± 1.21 (0–4) James and the Maths Test score, follow-up group, mean ± SD (range): G1: 1.76 ± 1.09 (0–4) G2: 1.91 ± 0.95 (0–4)^*^ | ERSSQ score. follow-up group, mean ± SD (range): Post-treatment: G1: 57.38 ± 13.40 (32–80) G2: 61.87 ± 8.91 (47–81)^*^ G1/BL: P < 0.001 G2/BL: P < 0.001 6 weeks: G1: 64.24 ± 9.27 (45–82) G2: 58.61 ± 11.99 (36–83)^*^ G1/BL: P < 0.001 G2/BL: P < 0.001 5-months: G1: 62.12 ± 12.90 (36–88) G2: 61.19 ± 10.96 (46–79)^*^ G1/BL: P < 0.001 G2/BL: P < 0.001 Emotion Recognition: Assessment of Perception of Emotion score, mean ± SD (range): Facial expression: G1: 19.92 ± 2.67 (13–24) G2: 19.73 ± 2.80 (15–24) ANOVA: time (P < 0.001), treatment (P = NS) Body posture: G1: 21.81 ± 2.97 (13–24) G2: 21.32 ± 2.82 (15–24) ANOVA: time (P < 0.02), treatment (P = NS) Assessment of Perception of Emotion score, follow-up group, mean ± SD (range):
| | | | Facial expression: Post-treatment: G1: 19.88 ± 2.71 (13–24) G2: 20.65 ± 2.46 (14–24)^*^ G1/BL: P < 0.05 G2/BL: P < 0.05 6 weeks: G1: 20.32 ± 4.76 (17–24) G2: 21.35 ± 2.31 (16–24)^*^ G1/BL: P = NS G2/BL: P = NS Body posture: Post-treatment: G1: 21.76 ± 3.02 (13–24) G2: 22.57 ± 1.95 (17–24)^*^ G1/BL: P < 0.05 G2/BL: P = NS 6 weeks: G1: 22.20 ± 2.52 (15–24) G2: 22.91 ± 1.98 (17–24)^*^ G1/BL: P < 0.05 G2/BL: P = NS Emotion Management: Dylan is Being Teased score, mean ± SD (range): G1: 5.08 ± 2.23 (2–10) G2: 2.64 ± 1.56 (0–7) G1/BL: P < 0.001 G2/BL: P = NS G1/G2: P < 0.05
| | | | Dylan is Being Teased score, follow-up group, mean ± SD (range): Post-treatment: G1: 5.16 ± 2.23 (2–10) G2: 4.04 ± 2.31 (1–10)^*^ G1/BL: P < 0.05 G2/BL: P < 0.05 6 weeks: G1: 4.36 ± 2.27 (1–9) G2: 4.22 ± 2.32 (1–9)^*^ G1/BL: P = NS G2/BL: P = NS James and the Maths Test score, mean ± SD (range): G1: 3.81 ± 1.58 (1–7) G2: 2.00 ± 1.11 (0–4) G1/BL: P < 0.001 G2/BL: P = NS G1/G2: P < 0.05 James and the Maths Test score, follow-up group, mean ± SD (range): Post-treatment: G1: 3.92 ± 1.50 (1–7) G2: 2.87 ± 1.63 (1–8)^*^ G1/BL: P < 0.05 G2/BL: P < 0.05 6 weeks: G1: 2.76 ± 1.33 (1–5) G2: 3.48 ± 2.02 (1–8)^*^ G1/BL: P = NS G2/BL: P < 0.05 Harms: NR Modifiers: NR

Comments:

* Once the treatment group completed the intervention, the program was offered to the wait-list group, so G2 constitutes another follow-up treatment group.

Ben Itzchak et al., 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Ben Itzchak et al., 2008 Country: Israel Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: Israeli Association for Children with Autism Author industry relationship disclosures: NR Design: Prospective case series Note: See related studies: Ben Itzchak et al., 2007{#538}, Zachor et al., 2007{#5652}, Zachor et al., 2009{#3844} (overlap among these not clear) | Intervention: Autism group: centerbased early-intervention program for 45 hrs/week Assessments: Cognitive ability: BSID-II for preverbal children, SB-FE for verbal children Autism severity: ADI, ADOS Cognitive assessments done for all participants, ADOS for only those with autism; re-examined after 1 year of intervention Head circumference measurements taken by senior child neurologist Groups: G1: autism Ga: normal cognitive score (IQ > 90) Gb: borderline cognitive score (70 < IQ < 89) Gc: low cognitive score (50 < IQ < 69) Provider:; - Child neurologist and multidisciplinary team at regional child development center (G2); - Not specified (G1); Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 44 G1a: 7 G1b: 18 G1c: 18 N at follow-up: G1: 44 G1a: 7 G1b: 18 G1c: 18 | Inclusion criteria:; - Children with autism (G1); Exclusion criteria:; - See inclusion criteria; Age, months (range): G1: 27.29 (19–35) G2: 24.16 (16–31) Mental age: NR Gender, n: Male: G1: 43 Female: G1: 1 Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In study Diagnostic tool/method: ADI-R and DSM-IV criteria Diagnostic category, n (%): Autism: G1: 44 (100) PDD-NOS: G1: 0 Aspergers: G1: 0 Cerebral palsy: G1: 0 Global developmental delay: G1: 0 Other characteristics: NR | Social skills: ADOS social interaction, mean ± SD: G1a: 14.42 ± 4.43 G1b: 16.18 ± 4.19 G1c: 21.79 ± 4.64 ADOS play, mean ± SD: G1a: 2.71 ± 1.50 G1b: 3.61 ± 1.33 G1c: 4.78 ± 0.94 Communication/language: ADOS language and communication, mean ± SD: G1a: 9.55 ± 2.64 G1b: 12.61 ± 3.22 G1c: 13.90 ± 5.11 Repetitive behavior: ADOS stereotyped behaviors, mean ± SD: G1a: 3.71 ± 2.43 G1b: 3.87 ± 1.64 G1c: 5.65 ± 1.78 Educational/cognitive/academic attainment: IQ, mean ± SD: G1: 74.84 ± 2.57 | Social skills: ADOS social interaction, mean ± SD: G1a: 8.44 ± 5.91 G1b: 11.72 ± 6.28 G1c: 15.94 ± 5.80 G1/BL: P < 0.001 ADOS play, mean ± SD: G1a: 2.14 ± 1.21 G1b: 1.94 ± 1.26 G1c: 3.22 ± 1.21 G1/BL: P < 0.001 Communication/language: ADOS language and communication, mean ± SD: G1a: 6.86 ± 3.72 G1b: 7.82 ± 3.24 G1c: 9.58 ± 4.24 G1/BL: P < 0.001 Repetitive behavior: ADOS stereotyped behaviors, mean ± SD: G1a: 2.29 ± 1.11 G1b: 3.37 ± 1.75 G1c: 4.89 ± 1.91 G1/BL: P < 0.05 Educational/cognitive/academic attainment: IQ, mean ± SD: G1: 89.66 ± 2.69 MANOVA: time (P < 0.001), time × group (P < 0.05) Harms: NR
| | | | Modifiers: Pre- and postintervention IQ scores inversely related with ADOS scores on language and communication (P < 0.05), social interaction (P < 0.01), play (P < 0.01), and stereotyped behaviors (P < 0.01)

Carr et al., 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Carr et al., 2008 Country: UK Practice setting: Academic Intervention setting: School Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: RCT Note: See related study Carr et al. 2007{#462} | Intervention: Six object-and-picture relations using highly preferred reinforcer pictures learned in earlier phases Both groups initially received discrimination teaching at baseline Error correction group: 6 subsequent teaching sessions, 1 per day with max of 2 days between sessions; each session comprised 5 conditional discrimination trials using standard error correction procedure followed by 5 correspondence checks Error prevention group: 6 subsequent teaching sessions; each session comprised 5 conditional trials using error prevention procedure followed by 5 correspondence checks Assessments: Picture Exchange Communication System Groups: G1: error correction G2: error prevention Provider: Experimenter Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: Total: 29 G1: 14 or 15 (NR) G2: 14 or 15 (NR) N at follow-up: Total: 29 | Inclusion criteria:; - Children with formal autism diagnosis by a clinical practitioner; - Age 3–7 years; - At Phase II of the Picture Exchange Communication System (able to make independent exchanges of pictures for items); Exclusion criteria:; - See inclusion criteria; Age, months: G1: 66 G2: 65 Mental age, months: PLS-3 receptive communication: G1: 8.4 G2: 8.6 PLS-3 expressive communication: G1: 8.4 G2: 7.6 VABS composite: G1: 15 G2: 15 Gender: NR Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: Diagnosis from clinical practitioner Diagnostic category, n (%): Autism: 29 (100) Other characteristics: NR | Educational/cognitive/academic attainment: Number of trials to mastery of conditional discriminations, mean (range): G1: 15 (10–40) G2: 15.3 (10–60) G1/G2: P = NS | Educational/cognitive/academic attainment: Correspondence trial accuracy rates, mean % (range): G1: 72.8 (30–97) G2: 92.7 (70–100) G1/G2: P < 0.01 Learning outcome accuracy rates, mean % (range): G1: 72.5 (39–100) G2: 91.7 (72–100) G1/G2: P < 0.03 Harms: NR Modifiers: NR

Corbett et al., 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Corbett et al., 2008 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: UC Davis MIND Institute Author industry relationship disclosures: NR Design: RCT, double-blind crossover design | Intervention: Tomatis Method: administration of prepared auditory stimulation recordings (2 hours/day filtered music, passed through Electronic Ear (for attenuation and modulation) and audio-vocal feedback; administered in 4 blocks, 3 weeks each for duration followed by break for 18 weeks. The second round (crossover design) for 18 more weeks. Placebo: commercially produced music without active microphone or Electronic Ear Assessments: Stanford Binet Intelligence Scale, PPVT-III, EOWVT; context of assessments not clear Groups: G1: treatment/placebo G2: placebo/treatment Provider: Two trained assistants Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies : NR N at enrollment: G1: 6 G2: 5 N at follow-up: G1: 6 G2: 5 | Inclusion criteria:; - DSM-IV diagnosis of autistic disorder corroborated by the ADOS-G and clinical judgment; - Able to speak 1–3 words; - Had a pointing gesture; - Tolerated wearing headphones; Exclusion criteria:; - Previous exposure to auditory stimulation treatments; Age, years (range): Total: 5.56 (3.5–7.17) G1: 5.25 (3.5–7.42) G2: 5.93 (4–7.17) Mental age: See baseline measures Gender, n (%): Male: 9 (82) Female: 2 (18) Race/ethnicity, n (%): Caucasian: 4 (36) Caucasian/Hispanic: 2(18) Hispanic: 2(18) Caucasian/Native American: 1 (9) Caucasian/Native American/Hispanic: 1 (9) Pacific Islander: 1 (9) SES: Maternal education: NR Household income: NR Diagnostic approach: In study Diagnostic tool/method: DSM-IV criteria confirmed by ADOS and clinical judgment Diagnostic category, n (%): Autism: 11 (100) Other characteristics: NR | Educational/ cognitive/ academic attainment: IQ mean, (range): 66.8 (52–83) Communication/ language: PPVT-III score, mean ± SD: G1: 20.83 ± 28.52 G2: 32.20 ± 25.21 EOWVT score, mean ± SD: G1: 16.50 ± 21.11 G2: 25.20 ± 19.82 | Educational/ cognitive/ academic attainment: IQ, mean, (range): 62.45 (44–84) Communication/ language: PPVT-III score, mean ± SD: Mid-treatment: G1: 20 ± 25.76 G2: 40.2 ± 26.69 Post-treatment: G1: 22.83 ± 29.36 G2: 47.2 ± 24.45 ANOVA: group (P = NS), time (P = 0.03), time × group (P = 0.08) EOWVT score, mean ± SD: Mid-treatment: G1: 18 ± 18.73 G2: 29.4 ± 22.65 Post-treatment: G1: 21.5 ± 23.3 G2: 34.4 ± 25 ANOVA: group (P = NS), time (P = 0.04), time × group (P = 0.63) Harms: NR Modifiers: NR

Fazlioglu et al., 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Fazlioglu et al., 2008 Country: Turkey Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: RCT | Intervention: Sensory integration program based on “The Sensory Diet”, administered in a specially arranged room at the center, 45 minutes per session, 2 sessions per week for 24 sessions total Control group, matched for age, gender, and level of function, attended regularly scheduled special education classrooms at the center, no sensory integration program Assessments: observations (administrator NR) Groups: G1: experimental G2: control group Provider: Special educator Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 15 G2: 15 N at follow-up: G1: 15 G2: 15 | Inclusion criteria:; - Low functioning children with autism; - Attended the Trakya University Training and Research Center for Mentally and Physically Handicapped Children; - Ages 7–11 years; Exclusion criteria:; - Previous participation in a sensory integration program; - History of epileptic seizures; Age, years (range): NR (7–11) Mental age: NR Gender, n (%): Male: G1: 12 (80) G2: 12 (80) Female: G1: 3 (20) G2: 3 (20) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: NR Diagnostic tool/method: DSM-IV Diagnostic category, n (%): Autism: 30 (100) Other characteristics: “majority” could not use language to communicate | Sensory: Sensory Evaluation for Children with Autism score, mean ± SD: G1: 98.2 ± 19.3 G2: 95.8 ± 17.0 | Sensory: Sensory Evaluation for Children with Autism score, mean ± SD: G1: 66.5 ± 11.4 G2: 97.3 ± 17.8 G1/G2: P < 0.01 Harms: NR Modifiers: NR

Greenberg et al., 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Greenberg et al., 2008 Country: US Practice setting: Community Intervention setting: School Enrollment period: September 2006 through August 2007 Funding: NR Author industry relationship disclosures: NR Design: Case series, retrospective | Intervention: Early intervention class at CCEI, ABA services provided in environment that combines discrete trial training and natural environment training by delivering learning units across the settings, 10 hours weekly for 44 weeks Assessments: Data Decision Analysis Protocol filled out daily by teachers and assistants Groups: G1: early intervention class at CCEI Provider: Teachers Measure of treatment fidelity reported: Yes: interobserver agreement ranged between 80% and 100% Co-interventions held stable during treatment: No Concomitant therapies: Majority of children’s programs were supplemented by 10 hours of homebased ABA special instruction N at enrollment: G1: 24 N at follow-up: G1: 24 | Inclusion criteria: NR Exclusion criteria: NR Age, mos. (range): (23–42) Mental age: NR Gender: M, n (%): NR F, n (%): NR Race/ethnicity, n (%): NR SES: Maternal education: NR Household income: NR Diagnostic approach: NR Diagnostic tool/method: NR Diagnostic category, n (%): PDD: 24 (100) Other characteristics, %: Severely limited speaker and listener skills, 80 1 child experienced Seizures at the start of CCEI | NR | Educational/ cognitive/ academic attainment: Learn Units, weekly: G1: (graph) Learn Units presented, total, mean (range): G1: 490, 807, 11155 (4413–15281) Learn Units correctly responded to, total, mean (range): G1: 315,680, 7175 (2871–10904) Learn Units presented per child per day, across the year mean (range): G1: 134 (100–168) Correct Learn Units per child per day, mean (range): G1: 86 (60–104) Classwide mean correct & total learn units per day for each child: G1: (graph) Total cumulative objectives mastered, n: G1: 2561 Average per child objectives mastered, n: G1: 107 Objectives met per week, n: G1: 58 Cumulative number of objectives met each week: G1: (graph) Learn units per objective, mean (range): G1: 213 (103–750) Weekly classwide mean learn units to criterion: G1: (graph) Students moving to lesser restrictive environments, %: G1: 95 Harms: NR Modifiers: NR

Kasari et al., 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Kasari et al., 2006 Kasari et al., 2008† Country: US Practice setting: Academic Intervention setting: School Enrollment period: NR Funding: NIH Author industry relationship disclosures: NR Design: RCT | Intervention: Symbolic play or joint attention intervention sessions for 30 minutes daily for 5–6 weeks Combination of adult-directed behavioral drill (approximately 5 minutes) and child-directed milieu teaching approach for approximately 20 minutes ABA and developmental procedures of responsive and interactive methods Semi-structured child-driven floor sessions with environmental adjustments to facilitate social and communicative attempts Number of sessions, mean ± SD: G1: 28.6 ± 15.6 G2: 34.7 ± 16.4 G1/G2: P = NS Assessments: MSEL, RDLS, ESCS, and Structured Play Assessment (parent report); parent-child observation (independent assessors) collected pre- and post-intervention and at 6 and 12 months post-intervention follow-up Groups: G1: joint attention G2: symbolic play G3: controls Provider: Graduate students in education psychology experienced with autistic children Measure of treatment fidelity reported: Yes Co-interventions held stable during treatment: NR | Inclusion criteria:; - Diagnosis of autism on the ADI-R and ADOS; - Age < 5 years old; - Accessible for follow-up; Exclusion criteria:; - Seizures; - Additional medical diagnoses (e.g., genetic syndromes); - Geographically inaccessible for follow-up visits; - Did not plan to stay in the early intervention program for at least 4 weeks; Age, months ± SD: Study entry: G1: 43.2 ± 7.05 G2: 42.67 ± 6.93 G3: 41.94 ± 4.93 Post-intervention: G1: 44.68 ± 6.86 G2: 44.60 ± 6.61 G3: 43.47 ± 5.06 12 month follow-up: G1: 58.25 ± 6.86 G2: 57.59 ± 6.74 G3: 56.63 ± 4.70 Mental age: See baseline measures Gender, n: Male: G1: 15 G2: 16 G3: 15 Female: G1: 5 G2: 5 G3: 2 Race/ethnicity, n (%): White: G1: 13 G2: 14 G3: 10 Minority: G1: 3 G2: 6 G3: 7 | Communication/ language: RDLS expressive language score, mean ± SD (range): G1: 20.60 ± 6.51 (17.55–23.65) G2: 21.43 ± 7.59 (17.97–24.89) G3: 19.41 ± 7.70 (15.45–23.37) RDLS receptive language score, mean ± SD (range): G1: 20.55 ± 7.27 (17.15–23.95) G2: 21.00 ± 9.75 (16.56–25.44) G3: 17.53 ± 8.70 (13.06–22.00) Social skills: ESCS score, mean ± SD: Showing: G1: 0.10 ± 0.31 G2: 0.52 ± 1.78 G3: 0.35 ± 0.61 Child joint attention looks: G1: 7.25 ± 6.05 G2: 11.9 ± 9.07 G3: 8.12 ± 6.75 Pointing: G1: 3.15 ± 14.95 G2: 9.62 ± 12.81 G3: 7.82 ± 11.96 Giving: G1: 3.65 ± 3.44 G2: 2.52 ± 3.06 G3: 3.59 ± 3.45 Responds joint attention: G1: 10.50 ± 5.42 G2: 11.91 ± 9.07 G3: 10.53 ± 6.49 | Communication/ language: RDLS expressive language score, mean ± SD (range): Post-intervention: G1: 23.15 ± 6.43 (20.14–26.16) G2: 23.67 ± 8.78 (19.67–27.88) G3: 21.18 ± 9.11 (16.49–25.86) 12 month follow-up:† G1: 35.70 ± 12.57 (29.82–41.59) G2: 38.29 ± 15.03 (30.57–46.02) G3: 28.06 ± 13.52 (20.86–35.27) RDLS receptive language score, mean ± SD (range): Post-intervention: G1: 22.80 ± 6.90 (19.57–26.03) G2: 24.12 ± 10.31 (19.43–28.81) G3: 18.76 ± 10.55 (13.34–24.19) 12 month follow-up:† G1: 31.85 ± 9.21 (27.54–36.16) G2: 35.06 ± 11.18 (29.31–40.81) G3: 27.31 ± 15.63 (18.99–35.64) Social Skills: ESCS score, mean ± SD: Showing: G1: 0.70 ± 1.19 G2: 1.29 ± 2.65 G3: 0.17 ± 0.53 G1/G2: P = NS G1/G3: P < 0.05 G2/G3: P < 0.05 ANOVA: time (P < 0.05)
| Concomitant therapies: NR N at enrollment: G1: 20 G2: 21 G3: 17 N at 6 month follow-up:† G1: 20 G2: 19 G3: 17 N at 12 month follow-up:† G1: 20 G2: 17 G3: 16 | SES: Maternal education, n: High school: G1: 0 G2: 3 G3: 2 Some college: G1: 2 G2: 4 G3: 4 College/professional: G1: 18 G2: 14 G3: 11 Household income: NR Diagnostic approach: In study Diagnostic tool/method: ADI-R, ADOS Diagnostic category, n (%): Autism: 58 (100) Other characteristics: NR | Joint attention initiations composite, mean ± SD (range):† G1: 3.95 ± 2.33 (2.86–5.04) G2: 4.32 ± 3.07 (2.92–5.71) G3: 3.29 ± 2.74 (1.88–4.70) Joint attention responses, mean ± SD (range):† G1: 10.05 ± 5.42 (7.96–13.04) G2: 10.24 ± 5.59 (7.69–12.78) G3: 10.52 ± 6.49 (7.19–13.87) Mother-child interaction, mean ± SD: Child joint attention looks: G1: 2.45 ± 3.35 G2: 2.33 ± 2.67 G3: 2.76 ± 4.19 Pointing: G1: 2.35 ± 4.04 G2: 2.62 ± 3.47 G3: 2.18 ± 3.52 Giving: G1: 1.65 ± 2.79 G2: 2.09 ± 2.68 G3: 1.47 ± 2.21 Showing: G1: 1.00 ± 1.34 G2: 2.90 ± 7.48 G3: 0.53 ± 0.71 Mother-child interaction, seconds ± SD: Child-initiated joint attention: G1: 140 ± 109 G2: 128 ± 179 G3: 229 ± 291 Mother-initiated joint attention: G1: 449 ± 191 G2: 432 ± 233 G3: 382 ± 226 | Child joint attention looks: G1: 9.55 ± 7.88 G2: 12.14 ± 9.30 G3: 10.35 ± 9.74 G1/G2: P = NS G1/G3: P = NS G2/G3: P = NS ANOVA: time (P < 0.05) Pointing: G1: 4.65 ± 15.60 G2: 9.76 ± 10.21 G3: 5.76 ± 7.57 G1/G2: P = NS G1/G3: P = NS G2/G3: P = NS ANOVA: time (P = NS) Giving: G1: 5.10 ± 3.54 G2: 3.05 ± 2.27 G3: 3.59 ± 2.40 G1/G2: P = NS G1/G3: P = NS G2/G3: P = NS ANOVA: time (P = NS) Responds joint attention: G1: 16.55 ± 6.64 G2: 12.04 ± 5.91 G3: 9.35 ± 6.00 G1/G2: P < 0.05 G1/G3: P < 0.05 G2/G3: P = NS ANOVA: time (P < 0.01), time × treatment (P < 0.01) Joint attention initiations composite, mean ± SD (range): Post-intervention: G1: 5.23 ± 3.14 (3.76–6.69) G2: 4.70 ± 3.40 (3.16–6.25) G3: 3.65 ± 2.89 (2.17–5.14)
| | | Mother-child interactions, mean ± SD: Functional types: G1: 5.33 ± 4.15 G2: 6.45 ± 4.84 G3: 5.71 ± 3.87 Symbolic types: G1: 1.76 ± 2.77 G2: 3.65 ± 4.73 G3: 3.12 ± 4.70 Level of play: G1: 4.89 ± 2.62 G2: 6.14 ± 2.61 G3: 5.70 ± 2.83 Adaptive behavior: Symbolic play level composite, mean ± SD (range):† G1: 6.44 ± 2.03 (5.49–7.39) G2: 5.37 ± 2.43 (4.26–6.48) G3: 6.18 ± 2.24 (5.02–7.33) Symbolic play types composite, mean ± SD (range): G1: 3.83 ± 3.84 (2.03–5.62) G2: 2.10 ± 2.54 (0.94–3.25) G3: 2.91 ± 3.23 (1.25–4.57) Structured play, mean ± SD: Functional types: G1: 18.95 ± 8.17 G2: 17.85 ± 8.57 G3: 20.76 ± 4.75 Symbolic types: G1: 2.43 ± 3.09 G2: 4.00 ± 5.16 G3: 2.71 ± 3.39 Level of play: G1: 5.86 ± 2.73 G2: 6.75 ± 2.27 G3: 6.65 ± 2.45 | 12 month follow-up:† G1: 6.44 ± 2.89 (5.09–7.79) G2: 7.92 ± 4.81 (5.45–10.39) G3: 2.91 ± 4.12 (0.71–5.10) G1/G2: P = NS G1/G3: P < 0.05 G2/G3: P < 0.05 Joint attention responses, mean ± SD (range): Post-intervention: G1: 16.55 ± 6.64 (13.44–19.66) G2: 12.05 ± 5.91 (9.36–14.74) G3: 9.35 ± 6.00 (6.27–12.44) 12 month follow-up:† G1: 10.00 ± 3.58 (8.22–11.78) G2: 10.88 ± 4.01 (8.82–12.95) G3: 9.30 ± 4.47 (6.10–12.50) G1/G2: P = NS G1/G3: P < 0.05 G2/G3: P < 0.05 Mother-child interaction, mean ± SD: Child joint attention looks: G1: 3.55 ± 5.38 G2: 3.47 ± 3.76 G3: 1.53 ± 1.77 G1/G2: P = NS G1/G3: P < 0.05 G2/G3: P < 0.05 ANOVA: time × treatment (P < 0.05)
| | | Educational/ cognitive/ academic attainment: Mental age, months ± SD: G1: 26.29 ± 8.71 G2: 24.55 ± 8.09 G3: 21.86 ± 9.26 Non-verbal composite age, months ± SD: G1: 28.65 ± 9.03 G2: 27.60 ± 6.74 G3: 24.34 ± 7.53 Developmental quotient, mean ± SD: G1: 58.30 ± 17.18 G2: 58.90 ± 18.21 G3: 51.98 ± 21.84 | Pointing: G1: 2.45 ± 3.10 G2: 3.71 ± 4.76 G3: 4.53 ± 7.00 G1/G2: P = NS G1/G3: P = NS G2/G3: P = NS ANOVA: time (P = NS) Giving: G1: 3.25 ± 2.95 G2: 1.28 ± 1.71 G3: 2.06 ± 3.61 G1/G2: P < 0.05 G1/G3: P = NS G2/G3: P = NS ANOVA: time × treatment (P < 0.05) Showing: G1: 2.65 ± 3.08 G2: 2.90 ± 4.25 G3: 1.23 ± 2.30 G1/G2: P < 0.05 G1/G3: P = NS G2/G3: P = NS ANOVA: time × treatment (P < 0.05) Mother-child interaction, child-initiated joint attention, seconds ± SD: Post-intervention: G1: 299 ± 237 G2: 212 ± 266 G3: 128 ± 188 G1/G2: P = NS G1/G3: P < 0.05 G2/G3: P = NS ANOVA: treatment (P < 0.05), time × treatment (P < 0.001)
| | | | 12 month follow-up:† G1: 363.55 ± 316.58 (215.39–511.71) G2: 309.00 ± 335.70 (136.40–481.60) G3: 129.40 ± 228.69 (2.76–256.05) G1/G2: P = NS G1/G3: P < 0.05 G2/G3: P < 0.05 Mother-child interaction, mother-initiated joint attention, seconds ± SD: Post-intervention: G1: 420 ± 194 G2: 521 ± 236 G3: 459 ± 207 G1/G2: P = NS G1/G3: P = NS G2/G3: P = NS ANOVA: time (P = NS) 12 month follow-up:† G1: 348.40 ± 259.69 (226.86–469.94) G2: 467.24 ± 277.21 (324.71–609.76) G3: 533.00 ± 242.12 (398.92–667.08) G1/G2: P = NS G1/G3: P = NS G2/G3: P = NS Mother-child interactions, mean ± SD: Functional types: G1: 7.43 ± 3.56 G2: 5.95 ± 4.20 G3: 5.23 ± 3.31 G1/G2: P = NS G1/G3: P = NS G2/G3: P = NS ANOVA: time (P = NS)
| | | | Symbolic types: G1: 5.48 ± 7.19 G2: 3.70 ± 4.28 G3: 2.58 ± 3.62 G1/G2: P < 0.05 G1/G3: P = NS G2/G3: P < 0.05 ANOVA: treatment (P < 0.001), time (P < 0.001), time × treatment (P < 0.001) Level of play: G1: 7.61 ± 2.75 G2: 7.47 ± 2.71 G3: 5.69 ± 2.42 G1/G2: P < 0.05 G1/G3: P = NS G2/G3: P < 0.05 ANOVA: treatment (P < 0.05), time (P < 0.001), time × treatment (P < 0.001) Adaptive Behavior: Symbolic play level composite, mean ± SD (range):† Post-intervention: G1: 7.21 ± 1.76 (6.38–8.04) G2: 7.61 ± 2.41 (6.52–8.71) G3: 6.05 ± 2.23 (4.91–7.19) 12 month follow-up: G1: 8.23 ± 2.46 (7.08–9.38) G2: 9.60 ± 1.73 (8.71–10.49) G3: 6.75 ± 2.46 (5.44–8.06) G1/G2: P < 0.05 G1/G3: P = NS G2/G3: P < 0.05
| | | | Symbolic play types composite, mean ± SD (range):† Post-intervention: G1: 5.00 ± 4.08 (3.09–6.91) G2: 5.0 ± 5.38 (2.55–7.45) G3: 2.85 ± 3.10 (1.26–4.45) 12 month follow-up: G1: 9.40 ± 7.58 (5.85–12.94) G2: 11.26 ± 7.89 (7.21–15.32) G3: 5.34 ± 8.50 (0.81–9.88) G1/G2: P = NS G1/G3: P = NS G2/G3: P < 0.05 Structured play, mean ± SD: Functional types: G1: 22.67 ± 6.51 G2: 24.00 ± 8.56 G3: 21.71 ± 6.82 G1/G2: P = NS G1/G3: P = NS G2/G3: P = NS ANOVA: time (P < 0.001) Symbolic types: G1: 4.52 ± 4.64 G2: 6.30 ± 6.65 G3: 3.12 ± 3.31 G1/G2: P = NS G1/G3: P = NS G2/G3: P = NS ANOVA: time (P < 0.001) Level of play: G1: 7.62 ± 2.75 G2: 6.95 ± 2.30 G3: 6.41 ± 2.60 G1/G2: P = NS G1/G3: P = NS G2/G3: P < 0.05 ANOVA: time × treatment (P < 0.05)
| | | | Educational/ cognitive/ academic attainment: Mental age, 12 month follow-up, months ± SD:† G1: 41.82 ± 12.09 G2: 40.33 ± 13.24 G3: 32.90 ± 14.54 Non-verbal composite age, 12 months follow-up, months ± SD:† G1: 47.37 ± 13.77 G2: 42.82 ± 14.08 G3: 35.87 ± 13.00 Harms: NR Modifiers: NR

Lopata et al., 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Lopata et al., 2008 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: Prospective cohort Note: See preliminary report of intervention, Lopata et al. 2006 ({#2697}) | Intervention: Manualized social treatment program Participants assigned to one of two performance feedback treatment conditions: response-cost or non-categorical feedback The response-cost group received feedback based on operationally defined behaviors, and the non-categorical feedback group received feedback but there were no predetermined behavioral categories on which feedback was based Each summer the program was administered for 6 weeks, five days/week for 6 hours each day; there were 4 treatment cycles each day, with each cycle beginning with a 20 minute structured social skills group and ending with a 50 minute therapeutic activity; social treatments were delivered in small groups of 6 children and 3 staff Assessments: By treatment staff, teachers, and parents: WISC-IV short form, BASC-PRS, BASC-TRS, Skillstreaming survey, DANVA2, Parent Satisfaction Survey Groups: G1: non-categorical G2: response-cost Provider: Psychology and education graduate students Measure of treatment fidelity reported: Yes | Inclusion criteria:; - Formal written diagnosis of AD, autism, or PDD-NOS by a licensed psychologist or psychiatrist; - WISC-IV short-form IQ composite > 70; - Index score ≥ 80 on at least one factor of the WISC-IV; - Absence of a current significant language delay; Exclusion criteria:; - Current significant language delay; Age, years ± SD: G1: 9.41 ± 2.31 G2: 9.6 ± 2.12 Mental age: Short-form IQ (WISC-IV), mean ± SD: G1: 97.56 ± 13.62 G2: 100.87± 17.92 Gender, n (%): Male: G1: 27 (93.1) G2: 23 (92) Female: G1: 2 (6.9) G2: 2 (8.0) Race/ethnicity, n (%): White: G1: 26 (89.7) G2: 22 (88) African American: G1: 1 (2.4) G2: 0 Latino: G1: 1 (1.9) G2: 1 (4) Other: G1: 2 (6.9) G2: 2 (8) SES: Parent education, years ± SD: G1: 15.83 ± 2.26 G2: 15.30 ± 2.37 Household income: NR | Social Skills: BASC social skills score, parent rated, mean ± SD: G1: 36.18 ± 7.00 (n=28) G2: 36.91 ± 8.81 (n=22) BASC social skills score, teacher rated, mean ± SD: G1: 47.38 ± 6.80 (n=28) G2: 43.52 ± 8.57 Adaptive behavior: BASC adaptive skills score, parent rated, mean ± SD: G1: 34.29 ± 7.17 (n=28) G2: 35.27 ± 8.69 (n=22) BASC adaptive skills score, teacher rated, mean ± SD: G1: 42.63 ± 6.53 (n=28) G2: 41.60 ± 6.92 BSI score, parent rated, mean ± SD: G1: 65.86 ± 11.50 (n=28) G2: 60.91 ± 10.88 (n=22) BSI score, teacher rated, mean ± SD: G1: 53.41 ± 9.33 (n=28) G2: 53.56 ± 7.70 Skillstreaming survey score, parent report, mean ± SD: G1: 104.28 ± 22.84 (n=25) G2: 103.15 ± 19.98 (n=20) Skillstreaming survey score, staff report, mean ± SD: G1: 118.59 ± 23.67 G2: 118.16 ± 19.52 | Social Skills: BASC social skills score, parent rated, mean ± SD: G1: 40.75 ± 8.37 (n=28; d=−0.59) G2: 38.59 ± 7.71 G1+G2/BL: P = 0.002 G1/G2: P = 0.153 BASC social skills score, teacher rated, mean ± SD: G1: 47.84 ± 6.25 (n=28; d=−0.07) G2: 46.76 ± 7.97 (d=−0.39) G1+G2/BL: P = 0.008 G1/G2: P = 0.067 Adaptive behavior: BASC adaptive skills score, parent rated, mean ± SD: G1: 37.79 ± 8.01 (n=28; d=0.45) G2: 36.05 ± 7.13 (n=22; d=0.1) G1+G2/BL: P = 0.011 G1/G2: P = 0.133 BASC adaptive skills score, teacher rated, mean ± SD: G1: 43.79 ± 5.89 (n=28; d=0.19) G2: 44.20 ± 5.98 (d=0.4) G1+G2/BL: P = 0.004 G1/G2: P = 0.291 BSI score, parent rated, mean ± SD: G1: 61.32 ± 9.78 (n=28; d=0.43) G2: 58.55 ± 11.71 (d=0.21) G1+G2/BL: P = 0.001 G1/G2: P = 0.295
| Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 29 G2: 25 N at follow-up: G1: 29 G2: 25 | Diagnostic approach: Referral/In-Study assessment Diagnostic tool/method: NR Diagnostic category, n (%): Autistic disorder: G1: 20 (69) G2: 16 (64) PDD-NOS: G1: 6 (20.7) G2: 6 (24) High-functioning autism: G1: 3 (10.3) G2: 3 (12) Other characteristics: NR | Problem behavior: BASC atypicality score, parent rated, mean ± SD: G1: 62.30 ± 13.06 (n=27) G2: 61.95 ± 11.88 (n=22) BASC atypicality score, teacher rated, mean ± SD: G1: 57.45 ± 11.64 (n=28) G2: 60.50 ± 13.28 BASC withdrawal score, parent rated, mean ± SD: G1: 64.61 ± 12.37 (n=28) G2: 65.50 ± 10.20 (n=22) BASC withdrawal score, teacher rated, mean ± SD: G1: 55.05 ± 10.24 (n=28) G2: 60.56 ± 10.27 Communication/ language: DANVA2 score, mean ± SD: Child faces: G1: 90.83 ± 21.25 (n=18) G2: 92.72 ± 17.98 (n=18) Adult faces: G1: 102.11 ± 9.68 (n=18) G2: 97.56 ± 14.35 (n=18) | BSI score, teacher rated, mean ± SD: G1: 56.96 ± 10.10 (n=28; d=0.37) G2: 52.52 ± 6.63 (d=0.14) G1+G2/BL: P = 0.049 G1/G2: P = 0.003 Skillstreaming survey score, parent report, mean ± SD: Parent report: G1: 116.04 ± 20.00 (n=25; d=0.55) G2: 113.60 ± 19.67 (n=20; d=0.53) G1+G2/BL: P < 0.001 G1/G2: P = 0.79 Skillstreaming survey score, staff report, mean ± SD: G1: 126.88 ± 18.50 (d=0.39) G2: 130.42 ± 17.67 (d=0.66) G1+G2/BL: P < 0.001 G1/G2: P = 0.395 Problem behavior: BASC atypicality score, parent rated, mean ± SD: G1: 58.89 ± 8.00 (n=27; d=0.31) G2: 59.67 ± 13.81 (n=22; d=0.1) G1+G2/BL: P = 0.075 G1/G2: P = 0.52 BASC atypicality score, teacher rated, mean ± SD: G1: 61.50 ± 13.72 (n=28; d=−0.32) G2: 59.04 ± 14.43 (d=0.11) G1+G2/BL: P = 0.15 G1/G2: P = 0.03
| | | | BASC withdrawal score, parent rated, mean ± SD: G1: 61.29 ± 12.79 (n=28; d=0.26) G2: 62.50 ± 9.03 (n=22; d=0.31) G1+G2/BL: P = 0.004 G1/G2: P = 0.887 BASC withdrawal score, teacher rated, mean ± SD: G1: 55.46 ± 10.11 (n=28; d=0.04) G2: 56.56 ± 9.44 (d=0.41) G1+G2/BL: P = 0.036 G1/G2: P = 0.028 Communication/ language: DANVA2 score, mean ± SD: Child faces: G1: 87.11 ± 22.37 (n=18; d=−0.17) G2: 89.22 ± 15.16 (n=18; d=−0.21) G1+G2/BL: P = 0.07 G1/G2: P = 0.963 Adult faces: G1: 101.39 ± 15.55 (n=18; d=−0.06) G2: 94.06 ± 13.86 (n=18; d=−0.25) G1+G2/BL: P = 0.166 G1/G2: P = 0.521 Harms: NR Modifiers: See above

Comments:

* In the outcomes column, d is the Cohen’s d effect size estimate for mean differences.

Ludlow et al., 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Ludlow et al., 2008 Country: UK Practice setting: Academic Intervention setting: School Enrollment period: NR Funding: NR Author industry relationship disclosures: 1 of 3 British Medical Research Council (royalties for intuitive overlays) Design: Prospective case series | Intervention: Three experiments to assess therapeutic benefits of colored overlays; participants selected the best color and side (matt or gloss) for clarity over text and as favorite over a blank sheet of paper Experiment 1 tested the rate of reading with and without colored overlays. Experiment 2 compared the rate of reading with overlays chosen for clarity vs. favorite color. Experiment 3 detected changes in visual stimuli with and without colored overlays in children with high and low functioning ability. Assessments: BPVS, rate of reading test, symptoms of visual stress (out of five) Groups: G1: Experiment 1 G2: Experiment 2 G3: Experiment 3 Ga: colored overlay, chosen for clarity Gb: colored overlay, chosen as favorite Gc: no colored overlay Provider: NR Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment:^*^ G1: 18 G2: 16 G3: 26 | Inclusion criteria:; - Diagnosis of ASD; - Recruited from schools for children with moderate learning difficulties with autism units; Exclusion criteria:; - See inclusion criteria; Age, years ± SD (range): G1: 12.3 ± 2.1 (9–15.83) G2: 14.8 ± 8.1 (14.1–15.83) G3: 12.3 ± 2.2 (9–15.83) Mental age: IQ score (Raven’s matrices), mean ± SD: G1: NR G2: 67.0 ± 5.3 G3: 75.8 ± 16.2 Gender, n (%): Male: G1: 18 (100) G2: 12 (75) G3: NR Female: G1: 0 G2: 4 (25) G3: NR Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: NR Diagnostic category, n (%): ASD: G1: 18 (100) G2: 16 (100) G3: 26 (100) Other characteristics: NR | Communication/language: BPVS score, mean ± SD: G1: 64.5 ± 11.2 G2: 59.6 ± 5.3 G3: NR | Communication/ language: Experiment 1: Symptoms of visual stress, mean ± SD: G1a: 0.06 ± 0.24 G1c: 0.39 ± 0.78 G1a/G1c: P < 0.05 Words read per minute, mean ± SD: G1a: 96.9 ± 33.7 G1c: 83.2 ± 32.3 G1a/G1c: P < 0.001 Experiment 2: Words read per minute, mean ± SD: G2a: 72.3 ± 29.2 G2b: 65.4 ± 29.7 G2c: 57.8 ± 36.8 G2a/G2c: P < 0.05 G2b/G2c: P < 0.05 G2a/G2b: P < 0.05 Experiment 3: Accuracy (out of 30) in sample matching task, mean ± SD: G3a: 26.8 ± 4.4 G3c: 26.4 ± 3.9 G3a/G3c: P = NS Time taken to complete sample matching task, seconds ± SD: G3a: 112.9 ± 57.0 G3c: 135.7 ± 60.1 G3a/G3c: P < 0.05 Harms: NR Modifiers: Experiment 3: There were no significant differences between low functioning and high functioning children with ASD. There was also no significant correlation between age or Raven’s matrices scores and time taken with or without overlays.
| N at follow-up:^*^ G1: 18 G2: 16 G3: 26

Comments:

* None of the partipants in Experiment 2 participated in Experiment 1 or 3, but 13 of the participants from Experiment 1 also participated in Experiment 3.

Meguid et al., 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Meguid et al., 2008 Country: Egypt Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: Non-randomized controlled trial | Intervention: Efalex supplement (blend of high DHA fish oil and evening primrose oil containing both omega 3 and 6 fatty acids as well as vitamin E) Children with autism (G1) received 2 capsules twice per day for 3 months; the controls (G2) were healthy and received no treatment or placebo Assessments: Blood levels of free PUFAs estimated from dried blood spot using tandem mass spectrometry; CARS at baseline and follow-up (3 months after treatment) Groups: G1: children with autism G2: healthy children, same age and gender Co-interventions held stable during treatment: NR Frequency of contact during study: NR Concomitant therapies: None N at enrollment: G1: 30 (28 families) G2: 30 N at follow-up: G1: 30 G2: NA | Inclusion criteria:; - Autism based on DSM-IV criteria and CARS scores; - Good physical health; - Not currently taking medications or essential fatty acid supplements during study; - Agree not to make changes in treatments for autism (medical, nutritional, behavioral, dietary) during the three months of the study; Exclusion criteria:; - See inclusion criteria; Age, yrs (range): NR (3–11) Mental age: NR Gender, n (%): Male: 18 (60) Female: 12 (40) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Department of Children with Special Needs Diagnostic tool/method: DSM-IV and CARS Diagnostic category, n (%): Autism: 30 (100) Other characteristics: NR | Overall ratings: CARS score, mean ± SD: G1: 39.5 ± 3.86 Medical: PUFA levels, mean ± SD: Linolenic: G1: 0.86 ± 0.44 G2: 3.2 ± 0.72 G1/G2: P < 0.0001 DHA: G1: 0.95 ± 0.2 G2: 2.85 ± 0.65 G1/G2: P < 0.0001 Linoleic: G1: 1.75 ± 0.46 G2: 2.77 ± 0.64 G1/G2: P < 0.0001 Arachidonic: G1: 2.5 ± 0.5 G2: 4.65 ± 0.5 G1/G2: P < 0.0001 AA/DHA: G1: 2.77 ± 0.84 G2: 1.71 ± 0.4 G1/G2: P < 0.0001 | Overall ratings: CARS score, mean ± SD: G1: 32.7 ± 3.37 G1/BL: P < 0.0001 Medical: PUFA levels, mean ± SD: Linolenic: G1: 1.76 ± 0.56 G1/BL: P < 0.0001 DHA: G1: 1.69 ± 0.42 G1/BL: P < 0.0001 Linoleic: G1: 2.32 ± 0.41 G1/BL: P < 0.0001 Arachidonic: G1: 3.23 ± 0.49 G1/BL: P < 0.0001 AA/DHA: G1: 2.01 ± 0.53 G1/BL: P < 0.0001 Harms: NR Modifiers: Correlation between CARS and baseline PUFA level, no significant improvement in autistic behavior (n=10): Linolenic: −0.471 (P > 0.05) DHA: −0.670 (P < 0.05) Linoleic: −0.118 (P > 0.05) AA: 0.115 (P > 0.05)
| | | | Correlation between CARS and post-treatment PUFA level, no significant improvement in autistic behavior (n=10): Linolenic: 0.395 (P > 0.05) DHA: −0.541 (P > 0.05) Linoleic: −0.287 (P > 0.05) AA: 0.262 (P > 0.05)

Nickels et al., 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Nickels et al., 2008 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: January 1976 to December 1997 Funding: Grant from Mr. and Mrs. David and Elaine Dana Author industry relationship disclosures: NR Design: Retrospective case series | Intervention: Population-based study of stimulant medication use in treatment of autism symptoms Assessments: Detailed chart review to abstract treatment information Episode of treatment: period of time subject treated with specific medication at specific dose, converted to methylphenidate equivalent units (MEUs) Groups: G1: stimulant medication G2: other treatment Ga: male Gb: female Co-interventions held stable during treatment: NR Frequency of contact during study: NR Concomitant therapies: NR N at enrollment: Total: 124 G1: 65 N at follow-up: NA | Inclusion criteria:; - Research identified autism; - Resident of Olmsted County, MN upon meeting DSM criteria; - IQ or DQ ≥ 35; - Age 21 and younger; Exclusion criteria:; - Diagnosis of Rett disorder, CDD, or schizophrenia prior to fulfilling DSM-IV criteria for autism; Age, onset of stimulant treatment, years (range): G1: 7.9 ± 2.9 (3.4–14.5) G1a: 7.0 ± 2.5 (3.4–14.2) G1b: 10.8 ± 2.4 (6.7–14.5) G1a/G1b: P < 0.001 Mental age: NR Gender, n (%): Male: Total: 95 (76.6) G1: 50 (76.9) Female: Total: 29 (23.4) G1: 15 (23.1) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: NR Diagnostic tool/method: Review of records noting any reference to autism symptoms as per an autism glossary developed from 182 children given diagnoses of autism in the medical diagnosis index at the Mayo Clinic. School and medical records of children with ≥ 2 symptoms noted were reviewed and all noted symptoms were evaluated using DSM-IV criteria | Overall measures: Medication use, n (%): Psychopharmacologic treatment: 82/124 (66) Psychostimulants: 65/124 (52) Number of stimulants used, n (%): One: G1: 32 (49) Two: G1: 19 (29) Three: G1: 14 (22) Total episodes of psychostimulant treatment, n: G1: 398 Episodes of psychostimulant treatment, median per child (range): G1: 5 (1–21) Type of stimulant used, n (%): Methylphenidate: G1: 52 (80) G1a: 41 (82) G1b: 11 (73) Dextroamphetamine: G1: 34 (52) G1a: 29 (58) G1b: 5 (33) Mixed amphetamine salts: G1: 13 (20) G1a: 11 (22) G1b: 2 (13) Pemoline: G1: 11 (17) G1a: 9 (18) G1b: 2 (13) Methamphetamine: G1: 2 (3) G1a: 2 (4) G1b: 0 | Overall measures: Duration of treatment, years ± SD (range): G1: 4.0 ± 3.9 (0.003–14.1) G1a: 4.5 ± 4.0 (0.008–14.1) G1b: 2.3 ± 2.8 (0.003–6.9) G1a/G1b: P = 0.03 Average daily dose, mg MEUs ± SD (range): G1: 27.3 ± 7.8 (2.5–75.2) G1a: 25.4 ± 15.3 (2.5–67.3) G1b: 34.1 ± 24.0 (5–75.2) Favorable response, n (%): G1: 276/398 (69) G1a: 235/345 (68) G1b: 41/53 (77) G1a/G1b: P = 0.33 Favorable response by stimulant episodes, n (%): Methylphenidate: 135/195 (69) Dextroamphetamine: 105/143 (73) Mixed amphetamine salts: 24/41 (59) Pemoline: 11/16 (69) Methamphetamine: 1/3 (33) Harms: Experienced at least one side effect, n (%): G1: 43/65 (66) G1a: 36/50 (72) G1b: 7/15 (47) G1a/G1b: P = 0.069
| | Diagnostic category, n (%): Autism: 124 (100) Other characteristics: Comorbid diagnoses, n (%):^*^ Speech/language: Total: 96 (77) Epilepsy: Total: 17 (14) Cognitive impairment (IQ/DQ < 70): Total: 68 (61) | | Side effects by stimulant episodes, n (%): Total: 67/398 (16.8) Methylphenidate: 31/195 (16) Dextroamphetamine: 24/143 (17) Mixed amphetamine salts: 7/41 (17) Pemoline: 4/16 (25) Methamphetamine: 1/3 (33) Methylphenidate side effects, n (# episodes): Tics: 4 (4) Appetite changes: 5 (6) Sleep disturbances: 6 (6) Headaches: 2 (2) Irritability/anxious-ness/worsening of behavior: 9 (10) Sedation/lethargy/ sleepiness: 3 (4) Other: 2 (2) Dextroamphetamine side effects, n (# episodes): Tics: 2 (3) Appetite changes: 3 (5) Sleep disturbance: 4 (6 ) Irritability/anxious-ness/worsening behavior: 10 (10) Sedation/lethargy/ sleepiness: 1 (1) Other: 1 (1) Unknown: 1 (1)
| | | | Mixed amphetamine salts side effects, n (# episodes): Tics: 1 (2) Sleep disturbances: 2 (2) Irritability/anxious-ness/worsening behavior: 3 (3) Other: 2 (3) Pemoline side effects, n (# episodes): Tics: 1 (1) GI complaints/ stomach ache: 1 (1) Other: 2 (2) Methamphetamine side effects, n (# episodes): Tics: 1 (1) Modifiers: No significant difference in rate of favorable response by type of stimulant used. No association between type of stimulant used and occurrence of side effects

Osborne et al., 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Osborne et al., 2008 Country: UK Practice setting: Academic Intervention setting: Home, school Enrollment period: 2003 to 2005 Funding: South East Regional Special Education Needs Partnership Author industry relationship disclosures: NR Design: Prospective cohort | Intervention: Teaching interventions: reinforcement (ABA-like with 1:1 in-home antecedent-behavior-conseuquence discrete trial training, with reinforcement), nursery (classes of 6–8 children with postgrad-trained teacher, plus 2–3 learning support assistants; some TEACCH methodology), speech/language, and parent training (on what is ASD and how to manage behaviors) Intervention types, n (%): Reinforcement: 49 (75) Nursery: 36 (55) Speech/language: 31 (48) Parent training: 11 (17) Reinforcement: 49 (75) Nursery: 36 (55) Number of interventions, n (%): 1: 21 (32) 2: 27 (42) 3: 16 (25) 4: 1 (1) Hours of intervention by type, mean ± SD (range):^*^ Reinforcement: 13.5 ± 10.7 (1–35) Nursery: 8.1 ± 5.5 (1–23) Speech/language: 1.2 ± 0.7 (1–3) Parent training: 4.2 ± 2.3 (1–10) Total intervention hours/ week: mean ± SD (range): 15.6 ± 9.2 (2–40) Groups: G1: low intensity (< 15.6 hours/week) intervention G2: high intensity (> 15.6 hours/week) intervention Ga: parenting stress (self-reported) below median Gb: parenting stress (self-reported) above median | Inclusion criteria:; - Age 2.6–4.0 years; - At the start of their first teaching intervention; - Independent prior ASD diagnosis from specialist pediatrician; - Initial referral from a general medical practitioner; - Statement of special education needs related to ASD from local education authorities; Exclusion criteria:; - See inclusion criteria; Age, years (range): NR (2.6–4.0) Mental age: See developmental age in baseline measures Gender, n (%): Male: 59 (90.1) Female: 6 (9.9) Race/ethnicity: NR SES: Maternal education, %: Secondary (16 yrs): 8 Tertiary (18 yrs): 33 Degree: 59 Postgraduate: 0 Paternal education, %: Secondary (16 yrs): 17 Tertiary (18 yrs): 17 Degree: 33 Postgraduate: 33 Maternal occupation, %: Unskilled/laborer: 33 Skilled/technical: 8 Managerial: 8 Unemployed/career houseworker: 50 Paternal occupation, %: Unskilled/laborer: 8 Skilled/technical: 17 Managerial: 75 Unemployed/career houseworker: 0 | Overall ratings: GARS score, mean ± SD: G1a: 90.7 ± 19.8 G1b: 95.8 ± 11.8 G2a: 90.7 ± 13.7 G2b: 90.6 ± 19.0 G1a/G1b/G2a/G2b: P = NS Adaptive behavior: VABS score, mean ± SD: G1a: 55.6 ± 4.7 G1b: 56.6 ± 6.2 G2a: 57.0 ± 6.6 G2b: 58.6 ± 11.0 G1a/G1b/G2a/G2b: P = NS VABS developmental age, months ± SD: G1a: 18.1 ± 3.6 G1b: 17.4 ± 6.7 G2a: 18.1 ± 5.4 G2b: 20.7 ± 13.6 G1a/G1b/G2a/G2b: P = NS Educational/ cognitive/ academic attainment: PEP-R score, mean ± SD: G1a: 51.3 ± 11.9 G1b: 53.7 ± 22.1 G2a: 54.0 ± 12.2 G2b: 57.2 ± 20.2 G1a/G1b/G2a/G2b: P = NS PEP-R developmental age, months ± SD: G1a: 21.7 ± 6.3 G1b: 21.9 ± 11.8 G2a: 21.9 ± 6.0 G2b: 25.2 ± 16.1 G1a/G1b/G2a/G2b: P = NS | Adaptive behavior: VABS score, 9–10 months, mean change ± SD: G1a: NR^**^ G1b: NR^**^ G2a: NR^**^ G2b: NR^**^ G1a/G1b: P = NS G2a/G2b: P < 0.05 G1a/G2a: P < 0.05 G1b/G2b: P = NS VABS developmental age, 9–10 months, months ± SD: G1a: NR^**^ G1b: NR^**^ G2a: NR^**^ G2b: NR^**^ G1a/G1b: P = NS G2a/G2b: P = NS G1a/G2a: P = NS G1b/G2b: P = NS Educational/ cognitive/ academic attainment: PEP-R score, 9–10 months, mean change ± SD: G1a: NR^**^ G1b: NR^**^ G2a: NR^**^ G2b: NR^**^ G1a/G1b: P = NS G2a/G2b: P = NS G1a/G2a: P < 0.05 G1b/G2b: P = NS
| Provider: Teachers, tutors (2–9, mean 4.2 ± 1.6), and/or parents Assessment:; - Autism severity by GARS; - Intellectual functioning by PEP-R; - Educational achievement by BAS-2; - Adaptive behavior and social functioning by VABS; - Self-report parental stress by QRS-F; - All testing conducted by an educational psychologist blind to intervention; Measure of treatment fidelity reported: No Co-interventions held stable during treatment: No Concomitant therapies, %: Dietary interventions: 60 Fringe crystal treatment: 1.5 N at enrollment: Total: 65 G1a: 25 G1b: 20 G2a: 9 G2b: 11 N at follow-up: Total: 65 G1a: 25 G1b: 20 G2a: 9 G2b: 11 | Marital status,%: Married: 83 Separated/divorced: 17 Household income: NR Diagnostic approach: Referral from specialized pediatrician based on clinical judgment, often with psychometric data In study confirmation Diagnostic tool/method: GARS Diagnostic category, n (%): Autism: 65 (100) Other characteristics: NR | BAS-II score, mean ± SD: G1a: 53.4 ± 9.1 G1b: 56.8 ± 14.0 G2a: 57.7 ± 19.0 G2b: 59.3 ± 20.7 G1a/G1b/G2a/G2b: P = NS BAS-II developmental age, months ± SD: G1a: 22.5 ± 5.5 G1b: 23.2 ± 9.7 G2a: 23.9 ± 11.2 G2b: 27.0 ± 18.4 G1a/G1b/G2a/G2b: P = NS Parenting Stress: QRS score, mean ± SD: G1a: 23.4 ± 5.3 G1b: 33.3 ± 4.7 G2a: 25.1 ± 4.4 G2b: 32.5 ± 4.1 | PEP-R developmental age, 9–10 months, months ± SD: G1a: NR^**^ G1b: NR^**^ G2a: NR^**^ G2b: NR^**^ G1a/G1b: P = NS G2a/G2b: P = NS G1a/G2a: P < 0.05 G1b/G2b: P = NS BAS-II score, 9–10 months, mean change ± SD: G1a: NR^**^ G1b: NR^**^ G2a: NR^**^ G2b: NR^**^ G1a/G1b: P = NS G2a/G2b: P < 0.05 G1a/G2a: P < 0.01 G1b/G2b: P = NS BAS-II developmental age, 9–10 months, months ± SD: G1a: NR^**^ G1b: NR^**^ G2a: NR^**^ G2b: NR^**^ G1a/G1b: P = NS G2a/G2b: P < 0.001 G1a/G2a: P < 0.001 G1b/G2b: P = NS Harms: NR Modifiers: Baseline QRS score was not associated with intervention intensity.
| | | | MANOVAs showed a significant effect of intervention intensity (P < 0.05), stress (P < 0.05), and stress × intensity (P < 0.05) for both standard scores and developmental age.

Comments:

* Means and standard deviations reported only within children who received the specified treatment

** Data only illustrated graphically.

Owens et al., 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Owens et al., 2008 Country: UK Practice setting: Academic Intervention setting: School Enrollment period: NR Funding: Medical Research Council Author industry relationship disclosures: NR Design: Non-randomized Control Trial | Intervention: LEGO Therapy and SULP (Social Use of Language Programme) One hour of group therapy per week for 18 weeks (over 5.5 months) LEGO: Collaborative LEGO play with projects divided into different roles, facilitated by adult super-visor SULP: direct teaching based on stories, activities, and games using stories, adult models, and children practicing to learn social and communication skills Assessments: Initial: Wechsler IQ, GARS, Spence Children’s Anxiety Scale, Conner’s ADHD and CDC. Outcome: VABS (socialization, communication and maladaptive behavior domains), GARS, parent satisfaction and child enjoyment, direct observation on school playground (examiner unblinded to group) Groups: G1: LEGO G2: SULP G3: controls^*^ Provider: First author (trained in LEGO therapy by Dr. LeGoff) with under-graduate volunteers who attended a one day training supervised by the first author Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR | Inclusion criteria:; - Current diagnosis of HFA, Aspergers, ASD, or autism by a clinical psychologist, psychiatrist, or pediatrician; - 6–11 years old; - IQ > 70; - Met cutoff on SCQ or ADI-R; - Able to speak on phrases; - Currently receiving no other behavioral intervention or social skills groups; - Attending mainstream education or an inclusion unit in a mainstream school; - No additional diagnoses of psychiatric disorders; Exclusion Criteria:; - See inclusion criteria; Age, months ± SD: G1: 99.13 ± 20.14 G2: 97.33 ± 22.33 G3: 105.81 ± 16.05 Mental age, mean ± SD: WASI FSIQ: G1: 113.93 ±16.97 G2: 106.87 ± 17.15 G3: 108 ± 14.48 WASI VIQ: G1: 110.4 ± 16.24 G2: 100.62 ± 22.62 G3: 105 ± 15.61 GARS AQ: G1: 81.75 ± 16.39 G2: 86.27 ± 13.53 G3: 93.19 ± 18.23 Gender, n (%): Male: G1: 16 (100) G2: 14 (93) G3: 16 (100) Female: G1: 0 G2: 1 (7) G3: 0 Race/ethnicity: NR | Overall ratings: GARS social interaction score, mean ± SD: G1: 7.94 ± 2.70 G2: 8.60 ± 2.97 G3: 8.75 ± 2.91 Social skills: Frequency of self-initiated social interactions, 10 minute playground observation, mean ± SD:^**^ G1: 9.09 ± 5.49 G2: 8.40 ± 6.34 Duration of self-initiated social interactions, 10 minute playground observation, mean ± SD:^**^ G1: 4.77 ± 2.25 G2: 4.96 ± 2.30 Adaptive behavior: VABS socialization score, mean ± SD: G1: 70.56 ± 12.13 G2: 63.73 ± 11.63 G3: 67.19 ± 11.51 VABS communication score, mean ± SD G1: 87.25 ± 14.89 G2: 74.13 ± 18.47 G3: 82.5 ± 23.94 VABS maladaptive behaviors score, mean ± SD G1: 17.75± 9.43 G2: 19.31 ± 7.89 G3: 23.19 ± 6.15 | Overall ratings: GARS social interaction score, mean ± SD: G1: 7.44 ± 2.20 G2: 9.27 ± 2.66 G3: 9.75 ± 3.36 G1/BL: P = NS G2/BL: P = NS G3/BL: P = NS G1/G2: P < 0.05 G1/G3: P < 0.05 G2/G3: P = NS Social skills: Frequency of self-initiated social interactions, 10 minute playground observation, mean ± SD:^**^ G1: 8.81 ± 7.32 G2: 7.20 ± 5.67 Duration of self-initiated social interactions, 10 minute playground observation, mean ± SD:^**^ G1: 6.66 ± 3.54 G2: 5.80 ± 2.30 G1/BL: P < 0.05 G2/BL: P = NS G1/G2: P = NS Adaptive behavior: VABS socializetion score, mean ± SD G1: 75.94 ± 14.86 G2: 71.33 ± 12.63 G3: 69.69 ± 13.23 G1/BL: P = NS G2/BL: P < 0.05 G3/BL: P = NS G1/G2: P = NS G1/G3: P = NS G2/G3: P = NS
| Concomitant therapies, n (%): G1: Speech and language: G1: 3 (19) G2: 4 (27) G3: 7 (44) OT: G1: 0 G2: 0 G3: 4 (25) GF/CF diet: G1: 1 (6) G2: 0 G3: 1 (6) N at enrollment: G1: 16 (in 5 groups) G2: 15 (in 5 groups) G3: 16 N at follow-up: G1: 16 G2: 15 G3: 16 | SES: Maternal education: NR Household income: NR Diagnostic approach: Referral, diagnosis was confirmed in study Diagnostic tool/method: ADI-R for G1 and G2; SCQ for G3 Diagnostic category, n (%): High functioning autism: G1: 5 (31) G2: 1 (7) G3: 2 (13) Aspergers: G1: 8 (50) G2: 8 (53) G3: 11 (69) ASD: G1: 2 (13) G2: 4 (27) G3: 2 (13) Autism: G1: 1 (6) G2: 2 (13) G3: 1 (6) Other characteristics: Educational support, n (%): Part-time TA: G1: 4 (25) G2: 4 (27) G3: 8 (50) Full time TA: G1: 7 (44) G2: 4 (27) G3: 2 (12.5) Inclusion unit: G1: 1 (6) G2: 3 (20) G3: 2 (12.5) | | VABS communication score, mean ± SD G1: 91.88 ± 18.83 G2: 83.13 ± 16.34 G3: 76.06 ± 17.17 G1/BL: P = NS G2/BL: P < 0.01 G3/BL: P = NS G1/G2: P = NS G1/G3: P = NS G2/G3: P = NS VABS maladaptive behaviors score, mean ± SD G1: 13.81 ± 5.23 G2: 16.69 ± 5.79 G3: 22.75 ± 5.52 G1/BL: P < 0.05 G2/BL: P = NS G3/BL: P = NS G1/G2: P = NS G1/G3: P < 0.05 G2/G3: P < 0.05 Harms: NR Modifiers: NR

Comments:

* Participants initially only recruited for G1 and G2; G3 participants were recruited at a later date as part of another study and asked if their data could be used for this study in a no intervention control group sample.

** In an unspecified subset of 21 of the 31 children in groups G1 and G2.

Perry et al., 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Perry et al., 2008 Country: Canada Practice setting: Academic Intervention setting: home, clinic, or child care center Enrollment period: NR Program data: 2000–2006 Funding: Ontario Ministry of Children and Youth Services Author industry relationship disclosures: NR Design: Retrospective case series | Intervention: Ontario IBI, 20 to 40 hours a week throughout the year in a variety of settings (home, center, and integrated child care) using structured behavioral teaching based on the principles of applied behavior analysis duration ranged from 4 to 47 months (mean 18 months) Assessments: CARS, VABS, and cognitive (most commonly used: MSEL, BSID, WPPSI, SB-FE) “typically conducted by assessment staff of the central agency”(p.627). Seven categories of progress/outcomes were generated based on all available information including developmental rates, VABS ABC, cognitive standard scores, and CARS. Groups: G1: IBI G1a: higher functioning (VABS ABC ≥ 60) G1b: intermediate functioning (VABS ABC between 50 and 59) G1c: lower functioning (VABS ABC ≤ 49) Provider: Instructor-therapists (virtually all had a college or university level education and all received same initial IBI training) who were supervised by Senior Therapists (had a Master’s degree and/or were Board Certified Behavior Analysts) Measure of treatment fidelity reported: No | Inclusion criteria:; - entry assessment within 3 months of entry; - another assessment (usually at exit); - diagnosis of autism or a disorder toward the severe end of the autism spectrum; Exclusion criteria:; - see inclusion criteria; Age, mean/yrs (range in months): 4.5 (20–86) Mental age, n, mean/months ± SD (range): (Combined scores from MSEL, BSID, WPPSI, and SB:FE) G1: 151, 22.92 ± 10.96 (3–60) G1a: 44, 28.24 ± 11.46 G1b: 66, 21.51 ± 10.61 G1c: 33, 17.64 ± 6.84 P < 0.001 Gender, n (%): M: 276 (83) F: 56 (17) Race/ethnicity, n (%): NR SES: Maternal education: NR Household income: NR Diagnostic approach: In Study Diagnostic tool/method: DSM-IV Diagnostic category, n (%): Autism 194 (58) PDD-NOS 46 (14) ASD/PDD 92 (28) Other characteristics: NR | Overall ratings: CARS, n, mean ± SD: G1: 275, 36.09 ± 5.09 G1a: 68, 33.48 ± 4.35 G1b: 105, 35.71 ± 4.43 G1c: 79, 38.91 ± 5.37 CARS symptom severity, n: Not quite autism range: 24 Mild/moderate autism range: 145 Severe autism range: 106 VABS/ABC, n, mean age equivalent ± SD: G1: 279, 16.81 ± 6.46 G1a: 72, 21.80 ± 7.96 G1b: 115, 16.16 ± 5.25 G1c: 9, 13.73 ± 3.73 VABS/ABC, n, mean standard score ± SD: G1: 274, 54.77 ± 9.24 G1a: 70, 66.90 ± 6.76 G1b: 116, 54.55 ± 3.00 G1c: 86, 45.65 ± 3.30 | Overall ratings: CARS, n, mean ± SD: G1: 275, 31.26 ± 5.31 P < 0.001 G1a: 68, 26.99 ± 4.93 P < 0.001 G1b: 105, 31.62 ± 4.14 P < 0.001 G1c: 79, 34.85 ± 4.61 P < 0.001 main effect of time: P < 0.001 reported reductions (P < 0.001) on each individual items of the CARS (with the exception of item XIV (P = 0.055)) CARS symptom severity changes, n (%): Non-autism remained non-autism: 19 (79) Non-autism to mild/moderate: 5 (21) Mild moderate to non-autism: 59 (41) Mild/moderate remained mild/moderate: 76 (52) Mild/moderate to severe: 10 (7) Severe to non-autism: 16 (15) Severe to mild/moderate: 63 (59) Severe remained severe: 27 (26) Children initially scoring in autism range changed to milder category: 138 (50)
| Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 332 G1a: 78 G1b: 126 G1c: 96 N at follow-up: G1: 332 G1a: 78 G1b: 126 G1c: 96 | | Social skills: VABS Socialization domain, n, mean age equivalent ± SD: G1: 279, 13.71 ± 6.34 G1a: 72, 18.60 ± 7.62 G1b: 115, 13.15 ± 5.37 G1c: 91, 10.56 ± 3.50 VABS Socialization domain, n, mean standard score ± SD: G1: 274, 56.69 ± 7.82 G1a: 70, 66.10 ± 8.68 G1b: 116, 55.49 ± 3.66 G1c: 86, 50.83 ± 2.47 Communication/ language: VABS Communication domain, n, mean age equivalent ± SD: G1: 281, 15.65 ± 8.86 G1a: 72, 22.29 ± 12.01 G1b: 115, 14.33 ± 6.24 G1c: 92, 12.18 ± 5.54 VABS Communication domain, n, mean standard score ± SD: G1: 273, 53.92 ± 11.34 G1a: 70, 68.23 ± 11.09 G1b: 116, 52.47 ± 4.30 G1c: 85, 44.51 ± 4.54 | VABS/ABC, n, mean age equivalent ± SD: G1: 279, 29.71 ± 14.21 P < 0.001 G1a: 72, 43.70 ± 14.48 P < 0.001 G1b: 115, 28.12 ± 10.83 P < 0.001 G1c: 91, 20.83 ± 8.20 P < 0.001 main effect of time P < 0.001 VABS/ABC, n, mean standard score ± SD: G1: 274, 56.26 ± 16.20 P = 0.02 G1a: 70, 75.79 ± 14.47 P < 0.001 G1b: 116, 54.28 ± 9.42 P = NS G1c: 86, 43.69 ± 7.32 P = 0.007 main effect of time P < 0.001 Categories of progress/ outcome, n (%): Average functioning: G1: 32 (10.8) G1a: 25 (32.5) G1b: 5 (4.2) G1c: 0 Substantial improvement: G1: 43 (14.5) G1a: 19 (24.7) G1b: 16 (13.4) G1c: 6 (6.5)
| | | Adaptive behavior: VABS Daily Living Skills domain, n, mean age equivalent ± SD: G1: 282, 20.90 ± 6.70 G1a: 73, 24.19 ± 8.25 G1b: 115, 20.99 ± 6.16 G1c: 92, 18.29 ± 4.58 VABS Daily Living Skills domain, n, mean standard score ± SD: G1: 274, 53.84 ± 12.10 G1a: 70, 66.36 ± 9.24 G1b: 116, 55.68 ± 5.24 G1c: 86, 41.99 ± 7.73 Motor skills: VABS Motor domain, n, mean age equivalent ± SD: G1: 167, 27.45 ± 7.59 G1a: 58, 28.71 ± 7.02 G1b: 69, 26.87 ± 7.60 G1c: 40, 26.63 ± 8.28 VABS Motor domain, n, mean standard score ± SD: G1: 138, 66.33 ± 13.95 G1a: 52, 76.94 ± 12.41 G1b: 66, 61.92 ± 10.10 G1c: 20, 53.30 ± 9.29 | Clinically significant improvement: G1: 90 (30.4) G1a: 18 (23.4) G1b: 43 (36.1) G1c: 28 (30.4) Less autistic: G1: 31 (10.5) G1a: 4 (5.2) G1b: 11(9.2) G1c: 14 (15.2) Minimal improvement: G1: 25 (8.4) G1a: 4 (5.2) G1b: 7 (5.9) G1c: 14 (15.2) No change: G1: 55 (18.6) G1a: 5 (6.5) G1b: 27 (22.7) G1c: 22 (23.9) Worse: G1: 20 (6.8) G1a: 2 (2.6) G1b: 10 (8.4) G1c: 8 (8.7) P < 0.001 Social skills: VABS Socialization domain, n, mean age equivalent ± SD: G1: 279, 24.28 ± 13.59 P < 0.001 G1a: 72, 36.65 ± 14.99 P < 0.001 G1b: 115, 22.58 ± 10.72 P < 0.001 G1c: 91, 16.79 ± 7.89 P < 0.001 main effect of time P < 0.001
| | | Educational/ cognitive/ academic attainment: FS IQ, n, mean ± SD: G1: 127, 47.42 ± 19.47 G1a: 40, 62.05 ± 15.99 G1b: 56, 43.44 ± 17.28 G1c: 26, 31.08 ± 9.90 Rate of developmental score, n, mean ± SD: G1: 278, 0.32 ± 0.12) G1a: 72, 0.47 ± 0.12 G1b: 114, 0.31 ± 0.06 G1c: 91, 0.22 ± 0.06 | VABS Socialization domain, n, mean standard score ± SD: G1: 274, 58.91 ± 12.07 P < 0.001 G1a: 70, 72.11 ± 13.11 P = 0.001 G1b: 116, 56.82 ± 7.69 P = NS G1c: 86, 51.63 ± 4.87 P = NS main effect of time P < 0.001 Communication/ language: VABS Communication domain, n, mean age equivalent ± SD: G1: 281, 32.12 ± 19.94 P < 0.001 G1a: 72, 52.31 ± 19.09 P < 0.001 G1b: 115, 29.26 ± 15.85 P < 0.001 G1c: 92, 20.30 ± 11.95 P < 0.001 main effect of time P < 0.001
| | | | VABS Communication domain, n, mean standard score ± SD: G1: 273, 59.13 ± 2216 P < 0.001 G1a: 70, 86.00 ± 20.45 P < 0.001 G1b: 116, 55.14 ± 14.09 P < 0.022 G1c: 85, 43.09 ± 8.60 P = NS main effect for time P < 0.001 Adaptive behavior: VABS Daily Living Skills domain, n, mean age equivalent ± SD: G1: 282, 32.60 ± 12.43 P < 0.001 G1a: 73, 42.21 ± 14.77 P < 0.001 G1b: 115, 32.50 ± 9.68 P < 0.001 G1c: 92, 25.24 ± 7.52 P < 0.001 main effect of time P < 0.001
| | | | VABS Daily Living Skills domain, n, mean standard score ± SD: G1: 274, 50.68 ± 17.89 P < 0.001 G1a: 70, 69.26 ± 16.62 P = NS G1b: 116, 50.89 ± 10.74 P < 0.001 G1c: 86, 36.00 ± 11.03 P < 0.001 main effect of time P < 0.001 Motor skills: VABS Motor domain, n, mean age equivalent ± SD: G1: 167, 43.52 ± 14.51 P < 0.001 G1a: 58, 50.98 ± 13.10 P < 0.001 G1b: 69, 42.12 ± 12.89 P < 0.001 G1c: 40, 35.13 ± 14.04 P < 0.001 main effect of time P < 0.001 VABS Motor domain, n, mean standard score ± SD: G1: 138, 68.47 ± 20.56 P = NS G1a: 52, 82.31 ± 18.10 G1b: 66, 62.08 ± 17.78 G1c: 20, 53.60 ± 13.72 main effect of time P = NS
| | | | Educational/ cognitive/ academic attainment: Mental age (Combined scores from MSEL, BSID, WPPSI, and SB-FE) mean/months ± SD: G1: 127, 41.40 ± 17.33 P < 0.001 G1a: 40, 54.77 ± 12.65 P < 0.001 G1b: 55, 38.40 ± 15.46 P < 0.001 G1c: 26, 25.56 ± 11.64 P = 0.002 main effect of time P < 0.001 Mental age changes, n (%): Gain of more than 12 months: 77 (61) Gain of 24 months or greater: 40 (32) Reduction of more than 12 months: 1 (0.8) Remained within 12 month of intake level: 48 (38) FS IQ mean ± SD: G1: 127, 59.28 ± 27.34 P < 0.001 G1a: 40, 82.67 ± 21.12 P < 0.001 G1b: 56, 53.74 ± 22.52 P < 0.001 G1c: 26, 33.08 ± 15.44 P = NS main effect for time P < 0.001
| | | | IQ changes, n (%): Increased by 15 points or more: 49 (39) Increased by 30 points or more: 22 (17) Decreased by 15 or more points: 3 (2) Remained within 15 points of initial score: 75 (59) Rate of developmental score, n, mean ± SD: G1: 278, 0.77 ± 0.76 P < 0.001 G1a: 72, 1.16 ± 0.95 P < 0.001 G1b: 114, 0.66 ± 0.59 P < 0.001 G1c: 91, 0.59 ± 0.69 P < 0.001 main effect of time P < 0.001 Developmental rate at or above typical development, n (%): G1a: 38 (53) G1b: 34 (30) G1c: 14 (15) Harms: NR Modifiers: CARS: group × time interaction: P = 0.004 FSIQ: group × time interaction: P < 0.001
| | | | MA: group × time interaction: P < 0.001 VABS Communication age equivalent, standard scores: group × time interaction: P < 0.001, P < 0.001 VABS Daily Living age equivalent, standard score: group × time interaction: P < 0.001, P < 0.001 VABS Socialization age equivalent, standard score group × time interaction: P < 0.001, P < 0.001 VABS Motor age equivalent, standard score group × time interaction: P < 0.001, P = NS VABS/ABC age equivalent, standard score group × time interaction: P < 0.001, P < 0.001. Developmental rate, group × time interaction: P = 0.006

Probst and Leppert, 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Probst and Leppert, 2008 Country: Germany Practice setting: Academic Intervention setting: School Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: Case series, prospective | Intervention: Teacher training in ASD symptoms, causes, assessment, treatment as well as educational skills focusing on antecedent interventions, methods of structured teaching and use of visual supports Three training sessions in two groups of 5 teachers each; one month between each session (months 1–3) Following group trainings, teachers had individual training sessions in the classroom for 6 months (months 4–9) Number of individual training sessions ± SD: 6 ± 1.25 Duration of individual training sessions, minutes ± SD: 30 ± 13 Assessments: Classroom Child Behavior Symptoms Questionnaire (CCBSQ) developed by authors, administered at baseline and the end of month 9 Groups: G1: teacher training Provider: 10 teachers (8 female) aged 42.0 ± 13.4 in two special education schools; each teacher had one child with ASD in a classroom of 8 ± 1.2 total children with MR. Teachers were trained by a graduate student who had competed a 5-day intensive TEACCH-training program Measure of treatment fidelity reported: No | Inclusion criteria:; - Met DSM-IV criteria for autism; Exclusion criteria:; - See Inclusion Criteria; Age, years ± SD: 10.0 ± 2.1 Mental age: NR Gender, n (%): Male: 7 (70) Female: 3 (30) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: Previous diagnosis of autism, as per school records; DSM-IV, CARS Diagnostic category, n (%): Autism: 10 (100) Severe Autism: 6 (66) Moderate Autism: 3 (33) Mild Autism: 1 (10) Other characteristics, n (%): Moderate or severe MR: 9 (90) Verbal language use: Never or seldom: 6 (60) Sometimes: 3 (30) Often: 1 (10) | Overall ratings: CARS score, mean ± SD: G1: 39.0 ± 7.0 Educational/cognitive/academic attainment: CCBSQ score, mean ± SD: G1: 106.4 ± 15.5 | Educational/cognitive/academic attainment: CCBSQ score, month 9, mean ± SD: G1: 100.8 ± 16.7 G1/BL: P < 0.05 Harms: NR Modifiers: NR
| Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 10 N at follow-up: G1: 10

Silva et al., 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Silva et al., 2008 Country: US Practice setting: Academic Intervention setting: Clinic and home Enrollment period: 2006 Funding: Spirit Mountain community fund Author industry relationship disclosures: NR Design: Case series, prospective Note: See related paper Silva et al., 2007 {#302} | Intervention: Qigong sensory training (QST) massage movements; 21 visits over 5 months, plus 15 minutes daily at home by parent QST trainers were recruited from the education service district and local health professionals. QST training consisted of skill-based curriculum and 50 hrs of didactic and experiential material. Trainers were observed by the PI delivering the 5 month intervention to two children. Assessments: VABS, Sensory Profile, Autism Behavior Checklist conducted by third party evaluators; parent-completed questionnaire RE observations of child’s behaviors Groups: G1: QST Provider: Professionals trained in QST, n: OT: 5 Autism specialist: 3 Teacher/educator: 2 OT assistant: 1 Instructional assistant: 1 Nurse: 1 Chiropractor: 1 Social worker: 1 Treatment manual followed: NR Defined protocol followed: Yes Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR | Inclusion criteria:; - < 6 years old; - Diagnosis of autism; - Enrolled in early intervention services; - No complicating medical diagnoses or medication (chelation agents); Inclusion criteria for QST trainers:; - Minimum 3 years experience working with children with autism; - Healthy and energetic (self assessment); - Not on medications for chronic health conditions; Age, months ± SD (range): 56.3 ± 12.5 (31–84) Mental age: NR Gender, n (%): Male: 21 (81) Female: 5 (19) Race/ethnicity: NR SES: NR Diagnostic approach: Referral Children were recruited who were receiving autism services from the education service district Diagnostic tool/method: NR Diagnostic category, n (%): Autism: 26 (100) Other characteristics: NR | Social skills: VABS score, mean ± SD: Socialization: G1: 70.9 ± 13.0 Communication/language: VABS Communication: G1: 68.5 ± 15.0 Adaptive behavior: VABS Composite: G1: 68.6 ± 12.2 VABS Daily living skills: G1: 73.3 ± 18.5 Motor skills: VABS Motor skills: G1: 73.5 ± 12.0 Sensory: Sensory profile score, mean ± SD: Total: G1: 21.0 ± 11.8 Processing: G1: 6.2 ± 3.7 Modulation: G1: 4.6 ± 3.3 Behavioral response: G1: 3.4 ± 1.9 Autism Behavior Checklist score, mean ± SD: G1: 66.0 ± 25.1 | Problem behavior: Autism Behavior Checklist score, mean ± SD: G1: 41.9 ± 22.1 P = 0.00005 Social skills: VABS socialization score, mean ± SD: G1: 79.8 ± 13.9 P = 0.003 Communication/language: VABS communication score, mean ± SD: G1: 77.6 ± 16.9 P = 0.0003 Adaptive behavior: VABS composite score, mean ± SD: G1: 77.7 ± 14.5 P = 0.00009 VABS daily living score, mean ± SD: G1: 82.7 ± 17.8 P = 0.003 Motor skills: VABS motor skills score, mean ± SD: G1: 81.0 ± 11.4 P = 0.003 Sensory: Sensory profile total score, mean ± SD: G1: 14.5 ± 10.7 P = 0.0003 Sensory processing score, mean ± SD: G1: 4.1 ± 3.4 P = 0.002
| Concomitant therapies: NR N at enrollment: G1: 26 N at follow-up: G1: 26 | | | Sensory modulation score, mean ± SD: G1: 3.2 ± 2.7 P = 0.003 Sensory behavioral response score, mean ± SD: G1: 2.8 ± 1.6 P = NS Harms: NR Modifiers: NR

Solomon et al., 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Solomon et al., 2008 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: Children’s Miracle Network Author industry relationship disclosures: NR Design: RCT | Intervention: Parent Child Interaction Therapy Phase 1: Child directed interaction, initially clinician led, then parents coached until reached mastery criteria (occurred within 8 sessions for all participants) Phase 2: Parent directed interaction, all parents completed within 6 sessions. Mean length of total treatment: 12.7 sessions (one family relocated in middle of CDI) Assessments: Parent rated ECBI, BASC, PSI-SF; DPICS affect coding done in free play session (G1 only) Groups: G1: intervention G2: control (waiting list) Provider: Five therapists (3 trained in PCIT with master trainers: shadowing and practicing at least 6 mos; 2 trained in team working with trained therapists) Measure of treatment fidelity reported: Regular team coding meetings during study, but no formal treatment fidelity measure taken Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 10 G2: 9 N at follow-up: G1: 10 G2: 9 | Inclusion criteria:; - Met DSM-IV-TR criteria for autistic disorder, aspergers disorder, or PDD-NOS; - Met cutoffs for ASD on ADOS; - Met cutoffs for autism on ADI-R; - Clinically significant externalizing behavior problems on BASC externalizing behavior scale OR exceed threshold on ECBI intensity scale; Exclusion criteria:; - FSIQ < 70 on WASI; - Not enough receptive or expressive language abilities to participate in language intensive intervention; Age, mean/yrs (range): G1: 8.2 ± 1.7 (6.0–10.8) G2: 8.1 ± 2.2 (5.3–12.1) Mental age: WASI FSIQ, mean ± SD: G1: 100.11 ± 19.2 (83–135) G2: 93.4 ± 16.8 (79–125) WASI VIQ, mean ± SD: G1: 97.7 ± 18.4 (73–138) G2: 90.4 ± 20.3 (75–133) WASI PIQ, mean ± SD: G1: 102.2 ± 21.6 (82–138) G2: 94.7 ± 9.3 (84–110) Gender, n (%): Male: 19 (100) Female: 0 Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral, with diagnosis Diagnostic tool/method: ADOS and ADI-R in study DSM-IV-TR | Overall ratings: ADOS score, mean ± SD (range): G1: 13.1 ± 4.3 (8–22) G2: 11.3 ± 3.6 (7–19) Problem behavior: ECBI intensity score, mean ± SD: G1: 67.0 ± 5.64 G2: 65.67 ± 8.80 ECBI problem score, mean ± SD: G1: 62.90 ± 6.30 G2: 66.78 ± 8.51 BASC externalizing score, mean ± SD: G1: 71.1 ± 8.2 G2: 76.6 ± 14.9 BASC aggression score, mean ± SD: G1: 63.90 ± 10.58 G2: 70.33 ± 14.21 BASC hyperactivity score, mean ± SD: G1: 74.30 ± 8.29 G2: 80.56 ± 13.95 BASC attention score, mean ± SD: G1: 72.80 ±6.13 G2: 70.89 ± 10.46 BASC conduct score, mean ± SD: G1: 67.40 ± 8.63 G2: 67.00 ± 14.03 Social skills: BASC adaptability score, mean ± SD: G1: 23.90 ± 7.91 G2: 28.44 ± 6.48 BASC social skills score, mean ± SD: G1: 30.20 ± 3.77 G2: 35.00 ± 10.52 BASC leadership score, mean ± SD: G1: 36.20 ± 4.02 G2: 33.89 ± 6.07 | Problem behavior: ECBI intensity score, mean ± SD: G1: 59.70 ± 4.95 G2: 62.22 ± 9.77 G1/BL: P = NS G2/BL: P = NS G1/G2: P = 0.462 ECBI problem score, mean ± SD: G1: 52.00 ± 6.52 G2: 63.00 ± 7.31 G1/BL: P = 0.015 G2/BL: P = NS G1/G2: P = 0.007 BASC aggression score, mean ± SD: G1: 59.00 ± 6.25 G2: 67.78 ± 14.60 G1/BL: P = NS G2/BL: P = NS G1/G2: P = 0.516 BASC hyperactivity score, mean ± SD: G1: 68.70 ± 11.68 G2: 80.56 ± 8.31 G1/BL: P = NS G2/BL: P = NS G1/G2: P = 0.055 BASC attention score, mean ± SD: G1: 65.80 ±8.77 G2: 70.67 ± 10.92 G1/BL: P = NS G2/BL: P = NS G1/G2: P = 0.062 BASC conduct score, mean ± SD: G1: 59.90 ± 8.01 G2: 66.00 ± 10.44 G1/BL: P = NS G2/BL: P = NS G1/G2: P = 0.059
| | Diagnostic category: Autism: G1: 4 G2: 4 PDD-NOS: G1 : 0 G2: 3 Aspergers: G1: 6 G2: 2 Other characteristics: NR | BASC depression score, mean ± SD: G1: 60.00 ± 9.57 G2: 72.33 ±15.68 BASC a typicality score, mean ± SD: G1: 75.50 ±14.25 G2: 72.33 ± 21.09 DPICS affect code score, mean ± SD: Shared positive affect: G1: 1.5 ± 1.8 (0–5) Parent positive affect: G1: 4.2 ± 2.5 (1–9) Child positive affect: G1: 4.8 ± 4.2 (0–12) Lag sequential: G1: 1.2 ± 1.6 (0–4) | Social skills: BASC adaptability score, mean ± SD: G1: 32.40 ± 10.23 G2: 27.33 ± 10.38 G1/BL: P = 0.002 G2/BL: P = NS G1/G2: P = 0.035 BASC social skills score, mean ± SD: G1: 37.40 ± 5.80 G2: 37.33 ± 6.91 G1/BL: P = NS G2/BL: P = NS G1/G2: P = 0.16 BASC leadership score, mean ± SD: G1: 38.10 ± 6.15 G2: 37.56 ± 4.72 G1/BL: P = NS G2/BL: P = NS G1/G2: P = 0.79 BASC depression score, mean ± SD: G1: 53.60 ± 7.25 G2: 65.11 ± 13.91 G1/BL: P = NS G2/BL: P = NS G1/G2: P = 0.089 BASC a typicality score, mean ± SD: G1: 69.10 ± 20.51 G2: 78.33 ± 17.11 G1/BL: P = NS G2/BL: P = NS G1/G2: P = 0.048 DPICS affect code score, mean ± SD: Shared positive affect: G1: 5.3 ± 5.2 G1/BL: P < 0.05 Parent positive affect: G1: 10.4 ± 5.7 G1/BL: P < 0.01
| | | | Child positive affect: G1: 7.3 ± 6.3 G1/BL: P < 0.1 Lag sequential: G1: 4.7 ± 4.9 G1/BL: P < 0.05 Harms: NR Modifiers: NR

Tyminski et al., 2008

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Tyminski et al., 2008 Country: US Practice setting: Community Intervention setting: School and home Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: Prospective case series | Intervention: Group psychotherapy, for an average 14 months for 2 groups of 6 and 3 groups of 5 Assessment: Social skills at home assessed by VABS and at school by the Social Skills Checklist; baseline social development by teachers Follow-up assessment of all study measures at 4 months to 3 years after start of study therapy Groups: G1: group psychotherapy Provider: Therapists Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 39 (100) N at follow-up: G1: 27 (69) | Inclusion criteria:; - Diagnosis of DSM-IV criteria for PDD; - Capacity for verbal communication; - No history of verbal aggression towards peers; Exclusion criteria:; - See inclusion criteria; Age, years (range): G1: 9.2 (5–16) Mental age: NR Gender, n (%): Male: 33 (85) Female: 6 (15) Race/ethnicity, n (%): White: 12 (31) Asian: 12 (31) Hispanic: 9 (23) African American: 2 (5) Multiracial: 4 (10) SES: Maternal education: NR Household income: NR Diagnostic approach: In Study Diagnostic tool/method: DSM-IV Diagnostic category, n (%): Autism: 15 (38) PDD-NOS: 21 (54) Aspergers: 3 (8) Other characteristics: Theory of Mind: NR | Social skills: VABS socialization, developmental age, months ± SD (range): G1: 33 ± 15.3 (13–86) Correlation between VABS and baseline measures: Age at intake: 0.38 (P < 0.05) Theory of Mind: 0.35 (P < 0.05) Social Skills Checklist score, mean ± SD (range): G1: 2.5 ± 0.8 (1.4–4.7) Correlation between SSC score and baseline measures: Age: 0.29 (P < 0.10) | Social skills: VABS socialization, developmental age, months ± SD (range): G1: 46 ± 18.2 (17–90) G1/BL: P < 0.001 Correlation between follow-up VABS and other measures: Theory of Mind: 0.49 (P < 0.01) Baseline VABS: 0.74 (P < 0.0001) Duration of therapy: −0.44 (P < 0.01) Social Skills Checklist score, mean ± SD (range): G1: 2.9 ± 0.7 (1.2–4.0) G1/BL: P < 0.01 Correlation between follow-up SSC score and other measures: Baseline SSC: 0.54 (P < 0.001) Correlation between change in SSC score and other measures: Age at intake: −0.32 (P < 0.10) Harms: NR Modifiers: Age at intake, theory of mind, and duration of therapy
Author: RUPP, 2007 Country: US Practice setting: Specialty treatment center Intervention setting: Clinic and home Enrollment period: NR Funding: NIH Author industry relationship disclosures: NR Design: Case series | Intervention: 11 parent education sessions covering prevention strategies, schedules, reinforcement, planned ignoring, compliance training, functional communication techniques, teaching techniques, and generalization; up to 4 optional sessions including time-out, contingency contracting, imitation training, and crisis management implemented at clinician discretion Mean parental adherence score for 11 mandatory sessions: 80 Assessments: Either WISC-III, MSEL, or LIPS-R, depending on the child’s cognitive functioning; Slosson Intelligence Test Parent(s) seen weekly for 75–90 minute parent training visits until week 14, and then for a home visit (week 17) and booster sessions (weeks 18, 20, and 22); initial home visit conducted between the week 2 and 3 parent training sessions Repeated measures collected at regular time points during the parent training program (baseline, weekly through week 8, monthly at weeks 12, 16, and 20, and study end-point at week 24): PTA, HSQ, ABC, CGI-I, VABS, PSI Groups: G1: parent training Provider: Parent training administered by therapists | Inclusion criteria:; - Age 4–13 years; - On stable medication for significant behavior problems (stable = on same medication dose for ≥ 4 weeks with no planned dosage changes for 6 months); - At least one parent available for training; - Met clinical DSM-IV criteria for Autistic Disorder, Asperger’s Disorder, or PDD-NOS; - CGI-S score of 3–5 at baseline; Exclusion criteria:; - IQ < 35 or mental age <18 months; Age, years ± SD: 7.7 ± 2.6 Mental age: IQ, mean ± SD: 55.9 ± 22.3 Gender, n: Male: 14 Female: 3 Race/ethnicity, %:^**^ White: 88 African American: 12 Asian: 6 Hispanic: 12 SES: Maternal education: NR Household income, %: < $20,000: 12 $20,001–$40,000: 18 $40,001–$60,000: 47 $60,001–$90,000: 23 Diagnostic approach: In Study Diagnostic tool/method: diagnosis using DSM-IV criteria made by experienced clinicians at each study site by interview and direct observation; diagnosis corroborated by ADI-R | Communication/language: ABLLS raw score, mean ± SD: G1: 133.4 ± 64.2 Problem behavior: ABC score, mean ± SD: Irritability: G1: 24.3 ± 9.3 Stereotypic behavior: G1: 8.8 ± 5.7 Lethargy/social withdrawal: G1: 9.5 ± 8.2 Hyperactivity/noncompliance: G1: 27.4 ± 9.5 Inappropriate speech: G1: 3.8 ± 3.6 PSI score, mean ± SD: G1: 114.1 ± 18 Adaptive behavior: VABS daily living skills score, mean ± SD: Raw score: G1: 119.9 ± 62.4 Standard score: G1: 38.3 ± 16.4 Age equivalency: G1: 35.7 ± 18.2 | Overall ratings: CGI-I rating, %: Very much improved/much improved: 53 Minimal improvement: 30 No change: 6 Parent rating of target behaviors improved, highly satisfied: 100 Communication/language: ABLLS raw score, week 24, mean ± SD: G1: 159 ± 56.4 G1/BL: P < 0.001 % change = 19.2 Problem behavior: ABC score, week 24, mean ± SD: Irritability: G1: 16.1 ± 9.5 33.8% reduction from BL G1/BL: P < 0.01 Stereotypic behavior: G1: NR G1/BL: P = NS Lethargy/social withdrawal: G1: NR G1/BL: P = NS Hyperactivity/noncompliance: G1: 21.7 ± 10.2 20.6% reduction from BL G1/BL: P < 0.05 Inappropriate speech: G1: NR G1/BL: P = NS
| Frequency of contact during study: Parent(s) seen weekly until week 14; home visit at week 17, booster sessions at weeks 18, 20, and 22; home visit between weeks 2 and 3 Measure of treatment fidelity reported: Yes Co-interventions held stable during treatment: Yes Concomitant therapies, %: Taking medication: 100 Enrolled in special education: 65 N at enrollment: G1: 17 N at follow-up: G1: 14^*^ | Diagnostic category, n: Autism: 11 PDD-NOS: 3 Aspergers: 2 Other characteristics,%: Living in 2-parent household: 88 Living in a parental home: 100 | | PSI score, week 24, mean ± SD: G1: 98.3 ± 17.7 13.9% reduction from BL G1/BL: P < 0.05 Adaptive behavior: VABS daily living skills score, week 24, mean ± SD: Raw score: G1: 146.7 ± 68.5 % change = 22.3 G1/BL: P < 0.01 Standard score: G1: 45.2 ± 18.2 % change = 18 G1/BL: P = NS Age equivalency: G1: 42.4 ± 22.2 % change = 18.7 G1/BL: P < 0.01 Harms: NR Modifiers: At 24 weeks: Correlation between adaptive behavior & improvement in the HSQ was r = 0.28

Comments:

* Reasons for study withdrawal: medication changes (1), medical problems (1), and parental unavailability (1).

** 18% selected more than one race category

## 2007

Baker-Ericzén et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Baker-Ericzén et al., 2007 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: 1999 to 2003 Funding: NIH Author industry relationship disclosures: NR Design: Prospective case series | Intervention: Pivotal Response Training (PRT): 12-week parent education program in which trained therapists taught parents strategies for increasing motivation Families met individually with therapist for 1 hour/week for 12 weeks Provider: Therapists conducting parent education (trained in PRT through graduate studies or a train-the trainer model with supervising psychologist; also trained in use of manual to teach techniques to parents) and master’s level developmental specialists or doctoral-level clinical psychologists with experience with children with ASD Assessments: VABS administered by therapist with parent at first and last treatment session Groups: G1: PRT Ga: males Gb: females Measure of treatment fidelity reported: Yes, but not after initial training Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 269 N at follow-up: G1: 158 | Inclusion criteria:; - Child with diagnosis of autistic disorder or PDDNOS by DSM-IV; Exclusion criteria:; - See inclusion criteria; Age, months (range): 49.36 (24–113) Age grouping, %: ≤ 3 years: 55 4–5 years: 35 ≥ 6 years: 10 Mental age: NR Gender, %: Male: 83 Female: 17 Race/ethnicity, %: Hispanic: 35.4 White: 27.4 Asian/Pacific Islander: 19.5 African American: 4 Native American: 2.7 Unknown/other: 10.6 SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: DSM-IV; not confirmed in study Diagnostic category, n (%): Autism/PDD-NOS: 158 (100) Other characteristics: NR | Social skills: VABS socialization score, mean ± SD: G1a: 59.65 ± 9.22 (n=136) G1b: 62.82 ± 10.47 (n=28) G1a/G1b: P = NS Communication/language: VABS communication score, mean ± SD: G1a: 58.93 ± 12.72 (n=136) G1b: 64.46 ± 13.87 (n=28) G1a/G1b: P = NS Motor skills: VABS motor skills score, mean ± SD: G1: NR^*^ Adaptive behavior: VABS composite score, mean ± SD: G1a: 54.50 ± 10.38 (n=128) G1b: 59.50 ± 10.81 (n=28) G1a/G1b: P < 0.05 VABS daily living skills score, mean ± SD: G1a: 56.54 ± 12.15 (n=135) G1b: 63.43 ± 12.23 (n=28) G1a/G1b: P = NS | Social skills: VABS socialization score, mean ± SD: G1a: 63.63 ± 11.70 (n=136) G1b: 67.82 ± 15.95 (n=28) G1a/BL: P < 0.001 G1a/BL: P < 0.01 G1/BL: P < 0.001 Communication/language: VABS communication score, mean ± SD: G1a: 63.61 ± 15.56 (n=136) G1b: 66.96 ± 15.44 (n=28) G1a/BL: P < 0.001 G1a/BL: P = NS G1/BL: P < 0.001 Motor skills: VABS motor skills score, mean ± SD: G1: NR^*^ G1/BL: P < 0.001 Adaptive behavior: VABS composite score, mean ± SD: G1a: 58.84 ± 12.32 (n=128) G1b: 64.75 ± 16.33 (n=28) G1a/BL: P < 0.001 G1a/BL: P < 0.01 G1/BL: P < 0.001
| | | | VABS daily living skills score, mean ± SD: G1a: 59.66 ± 12.74 (n=135) G1b: 66.36 ± 13.27 (n=28) G1a/BL: P < 0.001 G1a/BL: P < 0.01 G1/BL: P < 0.001 Harms: NR Modifiers: Significant effect for age with younger children (≤ 3 years) showing most improvement on the VABS composite score (P < 0.001) and older children (≥ 6 years) showing the least improvement (P < 0.01). No significant differences in domain scores by race at baseline.

Comments:

* The VABS motor skills score was only calculated for children under the age of 6 and is not reported.

Bauminger et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Bauminger et al., 2007 Country: Israel Practice setting: Academic Intervention setting: School Enrollment period: NR Funding: Israel Foundation Trustees Author industry relationship disclosures: NR Design: Retrospective case series Note: See related study with 11 overlapping participants, Bauminger et al., 2007{#422} | Intervention: Group-centered social multimodal Cognitive Behavioral-Ecological intervention: within teacher-led small groups of peers that included 2 typical peers and between 1 and 3 high functioning children with ASD. The research coordinator supported each teacher once monthly. Duration: 7 months Group lesson included teaching process to set “definitions and rules” for participants and practice process that allowed rehearsal of learned skills Social skills training consisted of 50 lessons focusing on group behavior and practicing behavior, covering:; - Instruction in prerequisite concepts for group involvement; - Affective education focusing mainly on higher processes of emotional understanding; - Group conversation skills; - Cooperative skills; - Double message issues; Assessments: Observed direct and indirect treatment effects on social cognitive capabilities, children’s change in overt cooperative skills within and outside the group. All measures administered once before and once after treatment. Groups: G1: individual intervention Ga: original group Gb: newly recruited | Inclusion criteria:; - Diagnosis of ASD from prior assessment by licensed psychologists using DSM-IV; Exclusion criteria:; - See inclusion criteria; Age, months ± SD: G1a: 105.4 ± 7.24 G1b: 110.78 ± 15.06 Mental age: Verbal IQ, mean ± SD: G1a: 104.09 ± 14.28 G1b: 110.62 ± 14.44 G1a/G1b: P = NS PIQ, mean ± SD: G1a: 109.73 ± 9.12 G1b: 116.92 ± 16.44 G1a/G1b: P = NS Full IQ, mean ± SD: G1a: 108.09 ± 8.62 G1b: 115.08 ± 13.68 G1a/G1b: P = NS Gender, n: Male: G1a: 10 G1b: 14 Female: G1a: 1 G1b: 1 Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referred from prior assessment by psychologists, diagnosis verified In Study Diagnostic tool/method: DSM-IV, ADI-R Diagnostic category, n: High functioning autism: G1a: 7 G1b: 10 Aspergers: G1a: 4 G1b: 5 | Social Skills: Specific companionship behaviors, mean ± SD: Mutual planning: G1: 1.69 ± 0.73 Cooperation: G1: 2.08 ± 1.16 Eye contact: G1: 2.50 ± 0.76 Negotiation: G1: 1.15 ± 0.36 Sharing: G1: 2.00 ± 0.93 Positive interaction, social behaviors, mean ± SD: Group: G1a: 8.27 ± 10.01 G1b: 9.86 ± 8.82 G1a/G1b: P = NS Dydactic: G1a: 25.45 ± 23.98 G1b: 34.86 ± 27.73 G1a/G1b: P = NS Low-level interaction, social behaviors, mean ± SD: Group: G1a: 14.09 ± 7.1 G1b: 10.73 ± 8.14 G1a/G1b: P = NS Dydactic: G1a: 15.36 ± 10.26 G1b: 21.00 ± 15.40 G1a/G1b: P = NS Negative interaction, social behaviors, mean ± SD: Group: G1a: 0.91 ± 1.22 G1b: 0.6 ± 1.12 G1a/G1b: P = NS Dydactic: G1a: 5.09 ± 5.32 G1b: 2.26 ± 2.21 G1a/G1b: P = NS | Social skills: Specific companionship behaviors, mean ± SD: Mutual planning: G1: 2.19 ± 0.84 G1/BL: P < 0.01 Cooperation: G1: 3.58 ± 1.39 G1/BL: P < 0.001 Eye contact: G1: 2.65 ± 1.12 G1/BL: P = NS Negotiation: G1: 1.23 ± 0.65 G1/BL: P = NS Sharing: G1: 2.58 ± 1.20 G1/BL: P < 0.05 Positive interaction, social behaviors, mean ± SD: Group: G1a: 4.36 ± 6.75 G1b: 14.26 ± 16.48 Dydactic: G1a: 29.45 ± 9.67 G1b: 27.73 ± 18.01 Low-level interaction, social behaviors, mean ± SD: Group: G1a: 14.36 ± 4.41 G1b: 11.86 ± 7.33 Dyadic: G1a: 11.09 ± 5.50 G1b: 14.86 ± 10.02 Negative interaction, social behaviors, mean ± SD: Group: G1a: 1 ± 1.34 G1b: 0.87 ± 1.41
| Provider: Special education teacher Measure of treatment fidelity reported: NR Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1a: 11 G1b: 15 N at follow-up: G1a: 11 G1b: 15 | Other characteristics: ADI social score, mean ± SD: G1a: 17.45 ± 3.90 G1b: 17.64 ± 3.62 G1a/G1b: P = NS ADI communication score, mean ± SD: G1a: 13.27 ± 4.88 G1b: 13.71 ± 4.28 G1a/G1b: P = NS ADI behavior score, mean ± SD: G1a: 5.00 ± 1.34 G1b: 5.79 ± 1.52 G1a/G1b: P = NS | Problem solving initiation behavior, mean ± SD: G1a: 4.72 ± 2.41 G1b: 4.33 ± 2.52 Number of social solutions, mean ± SD: G1a: 55.71 ± 17.80 G1b: 47.25 ± 17.74 TOM strange stories, mean ± SD: Comprehension: G1a: 4.45 ± 1.03 G1b: 4.13 ± 0.91 Justification: G1a: 3.63 ± 2.46 G1b: 4.2 ± 3.02 Executive function, mean ± SD: Number of sorts performed: G1a: 9.18 ± 2.18 G1b: 8.13 ± 4.27 Strategies generated: G1a: 9.18 ± 2.52 G1b: 8 ± 4.05 Strategies recognized: G1a: 9 ± 3.13 G1b: 7.40 ± 3.92 Emotional understanding: Recognition of emotion, mean ± SD: Basic: G1a: 10.90 ± 1.86 G1b: 11.60 ± 2.16 Complex: G1a: 11.18 ± 2.08 G1b: 10.46 ± 3.22 Relevancy of explanation, mean ± SD: Basic: G1a: 6.90 ± 1.04 G1b: 6.53 ± 1.76 Complex: G1a: 7.00 ± 0.77 G1b: 6.33 ± 1.45 | Dydactic: G1a: 6.09 ± 4.82 G1b: 2.46 ± 3.90 ANOVA: social behavior type (group/didactic; P < 0.001), group (newly recruited/original; P < 0.05) Problem solving initiation behavior, mean ± SD: G1a: 6.54 ± 4.03 G1b: 5.80 ± 2.33 G1/BL: P < 0.01 Number of social solutions, mean ± SD: G1a: 58.60 ± 23.74 G1b: 59.32 ± 13.99 G1/BL: P < 0.05 TOM strange stories, mean ± SD: Comprehension: G1a: 4.09 ± 1.37 G1b: 4.26 ± 0.45 G1/BL: P = NS Justification: G1a: 4.18 ± 2.35 G1b: 5.40 ± 2.35 G1/BL: P < 0.01 Executive function, mean ± SD: Number of sorts performed: G1a: 10.45 ± 2.84 G1b: 9.46 ± 2.94 G1/BL: P < 0.001 Strategies generated: G1a: 10.63 ± 2.84 G1b: 9.46 ± 2.92 G1/BL: P < 0.05 Strategies recognized: G1a: 10.27 ± 3.19 G1b: 7.80 ± 2.47 G1/BL: P < 0.05
| | | Definition accuracy, mean ± SD: Basic: G1a: 1.09 ± 1.51 G1b: 1.06 ± 1.33 Complex: G1a: 2.36 ± 2.01 G1b: 2.80 ± 2.56 Overall: G1a: 3.45 ± 3.41 G1b: 3.86 ± 3.64 Number of emotions described, mean ± SD: Basic: G1a: 3.45 ± 0.08 G1b: 3.40 ± 0.91 Complex: G1a: 4.18 ± 2.56 G1b: 4.27 ± 2.43 Overall: G1a: 8.54 ± 4.22 G1b: 7.66 ± 2.79 Audience awareness, mean ± SD: Basic: G1a: 4.15 ± 1.85 G1b: 5.31 ± 1.31 Complex: G1a: 9.56 ± 5.84 G1b: 9.58 ± 3.61 Overall: G1a: 13.71 ± 6.77 G1b: 14.89 ± 4.04 | Emotional understanding: Recognition of emotion, mean ± SD: Basic: G1a: 13.81 ± 2.27 G1b: 12.66 ± 2.59 G1/BL: P = 0.056 Complex: G1a: 12.27 ± 2.10 G1b: 13.20 ± 2.07 G1/BL: P = 0.056 Relevancy of explanation, mean ± SD: Basic: G1a: 7.81 ± 0.60 G1b: 7.46 ± 1.18 G1/BL: P = 0.056 Complex: G1a: 7.45 ± 0.82 G1b: 7.20 ± 0.94 G1/BL: P < 0.01 Definition accuracy, mean ± SD: Basic: G1a: 1.81 ± 1.40 G1b: 1.73 ± 1.33 G1/BL: P < 0.01 Complex: G1a: 4.63 ± 2.57 G1b: 3.80 ± 2.33 G1/BL: P = 0.056 Overall: G1a: 6.34 ± 3.61 G1b: 5.53 ± 3.29 G1/BL: P = 0.056 Number of emotions described, mean ± SD: Basic: G1a: 3.72 ± 0.05 G1b: 3.60 ± 0.63 G1/BL: P = NS Complex: G1a: 5.18 ± 2.13 G1b: 5.33 ± 2.16 G1/BL: P < 0.05
| | | | Overall: G1a: 8.90 ± 2.30 G1b: 8.93 ± 2.43 G1/BL: P = NS Audience awareness, mean ± SD: Basic: G1a: 4.75 ± 2.03 G1b: 5.62 ± 1.47 G1/BL: P = NS Complex: G1a: 12.71 ± 2.33 G1b: 11.38 ± 3.15 G1/BL: P < 0.05 Overall: G1a: 17.47 ± 4.01 G1b: 17.00 ± 3.73 G1/BL: P < 0.05 Harms: NR Modifiers: NR

Bauminger et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Bauminger et al., 2007 Country: Israel Practice setting: Academic Intervention setting: School Enrollment period: NR Funding: Israel Foundation Trustees Author industry relationship disclosures: NR Design: Retrospective case series Note: See related study with 11 overlapping participants, Bauminger et al., 2007{#422} | Intervention: Group-centered social multimodal Cognitive Behavioral-Ecological intervention: within teacher-led small groups of peers that included 2 typical peers and between 1 and 3 high functioning children with ASD. The research coordinator supported each teacher once monthly. Duration: 7 months Group lesson included teaching process to set “definitions and rules” for participants and practice process that allowed rehearsal of learned skills Social skills training consisted of 50 lessons focusing on group behavior and practicing behavior, covering:; - Instruction in prerequisite concepts for group involvement; - Affective education focusing mainly on higher processes of emotional understanding; - Group conversation skills; - Cooperative skills; - Double message issues; Assessments: Observed direct and indirect treatment effects on social cognitive capabilities, children’s change in overt cooperative skills within and outside the group. All measures administered once before and once after treatment. Groups: G1: individual intervention Ga: original group Gb: newly recruited | Inclusion criteria:; - Diagnosis of ASD from prior assessment by licensed psychologists using DSM-IV; Exclusion criteria:; - See inclusion criteria; Age, months ± SD: G1a: 105.4 ± 7.24 G1b: 110.78 ± 15.06 Mental age: Verbal IQ, mean ± SD: G1a: 104.09 ± 14.28 G1b: 110.62 ± 14.44 G1a/G1b: P = NS PIQ, mean ± SD: G1a: 109.73 ± 9.12 G1b: 116.92 ± 16.44 G1a/G1b: P = NS Full IQ, mean ± SD: G1a: 108.09 ± 8.62 G1b: 115.08 ± 13.68 G1a/G1b: P = NS Gender, n: Male: G1a: 10 G1b: 14 Female: G1a: 1 G1b: 1 Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referred from prior assessment by psychologists, diagnosis verified In Study Diagnostic tool/method: DSM-IV, ADI-R Diagnostic category, n: High functioning autism: G1a: 7 G1b: 10 Aspergers: G1a: 4 G1b: 5 | Social Skills: Specific companionship behaviors, mean ± SD: Mutual planning: G1: 1.69 ± 0.73 Cooperation: G1: 2.08 ± 1.16 Eye contact: G1: 2.50 ± 0.76 Negotiation: G1: 1.15 ± 0.36 Sharing: G1: 2.00 ± 0.93 Positive interaction, social behaviors, mean ± SD: Group: G1a: 8.27 ± 10.01 G1b: 9.86 ± 8.82 G1a/G1b: P = NS Dydactic: G1a: 25.45 ± 23.98 G1b: 34.86 ± 27.73 G1a/G1b: P = NS Low-level interaction, social behaviors, mean ± SD: Group: G1a: 14.09 ± 7.1 G1b: 10.73 ± 8.14 G1a/G1b: P = NS Dydactic: G1a: 15.36 ± 10.26 G1b: 21.00 ± 15.40 G1a/G1b: P = NS Negative interaction, social behaviors, mean ± SD: Group: G1a: 0.91 ± 1.22 G1b: 0.6 ± 1.12 G1a/G1b: P = NS Dydactic: G1a: 5.09 ± 5.32 G1b: 2.26 ± 2.21 G1a/G1b: P = NS | Social skills: Specific companionship behaviors, mean ± SD: Mutual planning: G1: 2.19 ± 0.84 G1/BL: P < 0.01 Cooperation: G1: 3.58 ± 1.39 G1/BL: P < 0.001 Eye contact: G1: 2.65 ± 1.12 G1/BL: P = NS Negotiation: G1: 1.23 ± 0.65 G1/BL: P = NS Sharing: G1: 2.58 ± 1.20 G1/BL: P < 0.05 Positive interaction, social behaviors, mean ± SD: Group: G1a: 4.36 ± 6.75 G1b: 14.26 ± 16.48 Dydactic: G1a: 29.45 ± 9.67 G1b: 27.73 ± 18.01 Low-level interaction, social behaviors, mean ± SD: Group: G1a: 14.36 ± 4.41 G1b: 11.86 ± 7.33 Dyadic: G1a: 11.09 ± 5.50 G1b: 14.86 ± 10.02 Negative interaction, social behaviors, mean ± SD: Group: G1a: 1 ± 1.34 G1b: 0.87 ± 1.41
| Provider: Special education teacher Measure of treatment fidelity reported: NR Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1a: 11 G1b: 15 N at follow-up: G1a: 11 G1b: 15 | Other characteristics: ADI social score, mean ± SD: G1a: 17.45 ± 3.90 G1b: 17.64 ± 3.62 G1a/G1b: P = NS ADI communication score, mean ± SD: G1a: 13.27 ± 4.88 G1b: 13.71 ± 4.28 G1a/G1b: P = NS ADI behavior score, mean ± SD: G1a: 5.00 ± 1.34 G1b: 5.79 ± 1.52 G1a/G1b: P = NS | Problem solving initiation behavior, mean ± SD: G1a: 4.72 ± 2.41 G1b: 4.33 ± 2.52 Number of social solutions, mean ± SD: G1a: 55.71 ± 17.80 G1b: 47.25 ± 17.74 TOM strange stories, mean ± SD: Comprehension: G1a: 4.45 ± 1.03 G1b: 4.13 ± 0.91 Justification: G1a: 3.63 ± 2.46 G1b: 4.2 ± 3.02 Executive function, mean ± SD: Number of sorts performed: G1a: 9.18 ± 2.18 G1b: 8.13 ± 4.27 Strategies generated: G1a: 9.18 ± 2.52 G1b: 8 ± 4.05 Strategies recognized: G1a: 9 ± 3.13 G1b: 7.40 ± 3.92 Emotional understanding: Recognition of emotion, mean ± SD: Basic: G1a: 10.90 ± 1.86 G1b: 11.60 ± 2.16 Complex: G1a: 11.18 ± 2.08 G1b: 10.46 ± 3.22 Relevancy of explanation, mean ± SD: Basic: G1a: 6.90 ± 1.04 G1b: 6.53 ± 1.76 Complex: G1a: 7.00 ± 0.77 G1b: 6.33 ± 1.45 | Dydactic: G1a: 6.09 ± 4.82 G1b: 2.46 ± 3.90 ANOVA: social behavior type (group/didactic; P < 0.001), group (newly recruited/original; P < 0.05) Problem solving initiation behavior, mean ± SD: G1a: 6.54 ± 4.03 G1b: 5.80 ± 2.33 G1/BL: P < 0.01 Number of social solutions, mean ± SD: G1a: 58.60 ± 23.74 G1b: 59.32 ± 13.99 G1/BL: P < 0.05 TOM strange stories, mean ± SD: Comprehension: G1a: 4.09 ± 1.37 G1b: 4.26 ± 0.45 G1/BL: P = NS Justification: G1a: 4.18 ± 2.35 G1b: 5.40 ± 2.35 G1/BL: P < 0.01 Executive function, mean ± SD: Number of sorts performed: G1a: 10.45 ± 2.84 G1b: 9.46 ± 2.94 G1/BL: P < 0.001 Strategies generated: G1a: 10.63 ± 2.84 G1b: 9.46 ± 2.92 G1/BL: P < 0.05 Strategies recognized: G1a: 10.27 ± 3.19 G1b: 7.80 ± 2.47 G1/BL: P < 0.05
| | | Definition accuracy, mean ± SD: Basic: G1a: 1.09 ± 1.51 G1b: 1.06 ± 1.33 Complex: G1a: 2.36 ± 2.01 G1b: 2.80 ± 2.56 Overall: G1a: 3.45 ± 3.41 G1b: 3.86 ± 3.64 Number of emotions described, mean ± SD: Basic: G1a: 3.45 ± 0.08 G1b: 3.40 ± 0.91 Complex: G1a: 4.18 ± 2.56 G1b: 4.27 ± 2.43 Overall: G1a: 8.54 ± 4.22 G1b: 7.66 ± 2.79 Audience awareness, mean ± SD: Basic: G1a: 4.15 ± 1.85 G1b: 5.31 ± 1.31 Complex: G1a: 9.56 ± 5.84 G1b: 9.58 ± 3.61 Overall: G1a: 13.71 ± 6.77 G1b: 14.89 ± 4.04 | Emotional understanding: Recognition of emotion, mean ± SD: Basic: G1a: 13.81 ± 2.27 G1b: 12.66 ± 2.59 G1/BL: P = 0.056 Complex: G1a: 12.27 ± 2.10 G1b: 13.20 ± 2.07 G1/BL: P = 0.056 Relevancy of explanation, mean ± SD: Basic: G1a: 7.81 ± 0.60 G1b: 7.46 ± 1.18 G1/BL: P = 0.056 Complex: G1a: 7.45 ± 0.82 G1b: 7.20 ± 0.94 G1/BL: P < 0.01 Definition accuracy, mean ± SD: Basic: G1a: 1.81 ± 1.40 G1b: 1.73 ± 1.33 G1/BL: P < 0.01 Complex: G1a: 4.63 ± 2.57 G1b: 3.80 ± 2.33 G1/BL: P = 0.056 Overall: G1a: 6.34 ± 3.61 G1b: 5.53 ± 3.29 G1/BL: P = 0.056 Number of emotions described, mean ± SD: Basic: G1a: 3.72 ± 0.05 G1b: 3.60 ± 0.63 G1/BL: P = NS Complex: G1a: 5.18 ± 2.13 G1b: 5.33 ± 2.16 G1/BL: P < 0.05
| | | | Overall: G1a: 8.90 ± 2.30 G1b: 8.93 ± 2.43 G1/BL: P = NS Audience awareness, mean ± SD: Basic: G1a: 4.75 ± 2.03 G1b: 5.62 ± 1.47 G1/BL: P = NS Complex: G1a: 12.71 ± 2.33 G1b: 11.38 ± 3.15 G1/BL: P < 0.05 Overall: G1a: 17.47 ± 4.01 G1b: 17.00 ± 3.73 G1/BL: P < 0.05 Harms: NR Modifiers: NR

Ben Itzchak and Zachor, 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Ben Itzchak and Zachor, 2007 Country: Israel Practice setting: Academic Intervention setting: Clinic and home Enrollment period: NR Funding: Israeli Ministry of Education Author industry relationship disclosures: NR Design: Prospective case series Note: See related studies: Ben Itzchak et al., 2007, Zachor et al., 2007, Zachor et al., 2009 (overlap among these not clear) | Intervention: Center-based ABA program with one-on-one therapy with behavioral therapists for at least 35 hours/week and behavioral methods used at home by parents Assessments: Pre- and post-treatment (1 year): ADI-R, ADOS, BSID-II, Stanford-Binet Intelligence Scale, 4^th^ ed. Developmental-behavioral scales, all administered by therapists and scores provided by blinded raters Groups: G1: intervention Ga: low-IQ (50–70) at baseline Gb: high-IQ (71–103) at baseline Gc: score ≥ 16 on ADOS-module I reciprocal-social interaction (low social) Gd: score < 16 on ADOS-module I reciprocal-social interaction (high social) Provider: Planning and supervision by trained behavior analyst; provided by skilled behavioral therapists and by parents Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 25 G1a: 12 G1b: 12 G1c: 12 G1d: 12 N at follow-up: G1: 25 | Inclusion criteria:; - Age < 32 months; - Diagnosed with autism; Exclusion criteria:; - Certain comorbidities (e.g., seizure disorder; genetic syndromes); Age, mean months (range): 26.6 (20–32) Mental age: NR Gender, n (%): Male: 23 (92) Female: 2 (8) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In Study Diagnostic tool/method: ADI-R, ADOS protocols, and DSM-IV criteria for autism assessed by an independent clinician Diagnostic category, n (%): Autism: 25 (100) PDD-NOS: 0 Aspergers: 0 Other characteristics, n (%): Expressive vocabulary < 10 words, n: 24 Expressive vocabulary: two-word utterances, n: 1 | Social skills: Play skills score, mean ± SD: G1: 0.92 ± 1.19 G1a: 0.33 ± 0.89 G1b: 1.33 ± 1.15 G1c: 0.67 ± 1.15 G1d: 1.25 ± 1.21 Communication/language: Imitation score, mean ± SD: G1: 2.36 ± 2.61 G1a: 0.91 ± 1.73 G1b: 3.42 ± 2.54 G1c: 1.08 ± 1.72 G1d: 3.83 ± 2.69 Receptive language score, mean ± SD: G1: 1.64 ± 1.87 G1a: 0.67 ± 1.15 G1b: 2.42 ± 2.02 G1c: 1.00 ± 1.28 G1d: 2.41 ± 2.15 Expressive language, mean ± SD: G1: 0.76 ±1.69 G1a: 0.83 ± 0.28 G1b: 1.25 ± 2.22 G1c: 0.25 ± 0.45 G1d: 1.33 ± 2.31 Nonverbal skills, mean ± SD: G1: 0.80 ± 0.76 G1a: 0.42 ± 0.51 G1b: 1.08 ± 0.79 G1c: 0.58 ± 0.51 G1d: 1.08 ± 0.90 Repetitive behavior: Stereotyped behaviors, mean ± SD: G1: 6.48 ± 3.23 G1a: 7.58 ± 2.97 G1b: 5.92 ± 2.91 G1c: 7.58 ± 2.27 G1d: 5.42 ± 3.87 | Social skills: Play skills score, mean ± SD: G1: 3.16 ± 1.62 G1a: 2.08 ± 1.44 G1b: 4.17 ± 1.11 G1c: 2.33 ± 1.37 G1d: 4.00 ± 1.53 G1/BL: P < 0.001 G1a/BL: P < 0.001 G1b/BL: P < 0.001 G1c/BL: P < 0.001 G1d/BL: P < 0.001 G1a/G1b: P = 0.07 G1c/G1d: P = NS Communication/language: Imitation score, mean ± SD: G1: 8.00 ± 1.44 G1a: 7.08 ± 1.62 G1b: 8.83 ± 0.39 G1c: 7.50 ± 1.44 G1d: 8.41 ± 2.62 G1/BL: P < 0.001 G1a/BL: P < 0.001 G1b/BL: P < 0.001 G1c/BL: P < 0.001 G1d/BL: P < 0.001 G1a/G1b: P < 0.01 G1c/G1d: P < 0.05
| | | Educational/cognitive/academic attainment: IQ, mean ± SD: G1: 70.67 ± 17.01 G1a: 61.00 ± 12.10 G1b: 80.45 ± 15.15 | Receptive language, mean ± SD: G1: 6.28 ± 2.34 G1a: 4.75 ± 2.26 G1b: 7.58 ± 1.31 G1c: 4.91 ± 2.19 G1d: 7.58 ± 1.78 G1/BL: P < 0.001 G1a/BL: P < 0.001 G1b/BL: P < 0.001 G1c/BL: P < 0.001 G1d/BL: P < 0.001 G1a/G1b: P < 0.05 G1c/G1d: P = NS Expressive language, mean ± SD: G1: 5.84 ± 3.69 G1a: 3.67 ± 3.14 G1b: 7.67 ± 3.08 G1c: 3.50 ± 3.12 G1d: 7.92 ± 2.91 G1/BL: P < 0.001 G1a/BL: P < 0.001 G1b/BL: P < 0.001 G1c/BL: P < 0.001 G1d/BL: P < 0.001 G1a/G1b: P = NS G1c/G1d: P = 0.09
| | | | Nonverbal skills, mean ± SD: G1: 2.00 ± 0.76 G1a: 1.50 ± 0.52 G1b: 2.42 ± 0.67 G1c: 1.58 ± 0.51 G1d: 2.42 ± 0.79 G1/BL: P < 0.001 G1a/BL: P < 0.001 G1b/BL: P < 0.001 G1c/BL: P < 0.001 G1d/BL: P < 0.001 G1a/G1b: P = NS G1c/G1d: P = NS Repetitive behavior: Stereotyped behaviors, mean ± SD: G1: 3.36 ± 2.62 G1a: 4.33 ± 2.50 G1b: 2.67 ± 2.50 G1c: 4.75 ± 2.26 G1d: 2.08 ± 2.42 G1/BL: P < 0.001 G1a/BL: P < 0.001 G1b/BL: P < 0.001 G1c/BL: P < 0.001 G1d/BL: P < 0.001 G1a/G1b: P = NS G1c/G1d: P = NS Educational/cognitive/academic attainment: IQ, mean ± SD: G1: 87.90 ± 16.56 G1c: 76.82 ± 17.32 G1d: 96.50 ± 10.45 G1/BL: P < 0.001 G1c/BL: P < 0.001 G1d/BL: P < 0.001 G1c/G1d: P = NS
| | | | Harms: NR Modifiers: Post-intervention scores for G1b were significantly greater than G1a on imitation (P < 0.01) and receptive language (P < 0.05). Post-intervention scores for G1d were significantly greater than G1c on imitation (P < 0.05). Higher IQ scores correlated with fewer deficits in social interaction as measured by ADOS (P < 0.01), ADOS-language and communication scores (P = 0.09)

Carr and Felce, 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Carr and Felce, 2007 Country: UK Practice setting: Academic Intervention setting: School Enrollment period: NR Funding: Healthcare Foundation (formerly PPP Foundation) Author industry relationship disclosures: NR Design: Non randomized controlled trial Note: See related study Carr et al., 2007 ({#165}) | Intervention: PECS intervention: 15 hours of PECS teaching over 5 weeks; 3–4 PECS teaching days/week with a total of 1 hour teaching delivered over 2–3 sessions on each PECS teaching day Controls had two 2 hour observations separated by a 5 week interval without PECS teaching Assessments: VABS and PLS-3UK at baseline; observation instrument to record communication interactions between children and teachers 6 weeks before, during the week prior and during the week following teaching Groups: G1: PECS G2: controls Provider: 2 researchers trained to deliver PECS teaching Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 24 G2: 17 N at follow-up: G1: 24 G2: 17 | Inclusion criteria:; - Age 3–7 years; - Previous diagnosis of autism from a clinical practitioner, verified through their classroom teachers from the child’s Statement of Special Educational Needs; - Attending special education classrooms or units for autism; - Received no previous PECS teaching beyond Phase I (G1); - Within 50 miles from the researchers’ base and child’s school agreed to participate (G1); - No PECS teaching anytime (G2); - Outside the 50 mile limit (G2); Exclusion criteria:; - See Inclusion criteria; Age, months: G1: 65 G2: 69 Mental age: NR Gender: NR Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: Previous diagnosis of autism from a clinical practitioner Diagnostic category, n (%): Autism: 41 (100) PDD-NOS: NR Aspergers: NR Other characteristics: NR | Overall ratings: VABS score, developmental age, months: Daily living skills: G1: 16.5 G2: 15.9 Social interaction: G1: 12.0 G2: 12.5 Composite: G1: 14.7 G2: 14.8 PLS-3UK developmental age, months: Receptive: G1: 7.8 G2: 8.6 Expressive: G1: 7.4 G2: 9.8 Composite: G1: 7.7 G2: 9.4 Communication/language: Child-to-adult total initiations, mean: G1: 11.1 G2: 12.6 Child-to-adult total initiations, 6 weeks before intervention, mean: G1: 9.9 Child-to-adult linguistic initiations: G1: 0.7 G2: 2 Adult response, mean %: G1: 67.10 G2: 78.35 Child-to-adult linguistic initiations, 6 weeks before intervention, mean: G1: 0.4 | Communication/language: Child-to-adult total initiations, mean: G1: 61.4 G2: 10 G1/BL: P < 0.001 G2/BL: P = NS G1/G2: P < 0.00003 Child-to-adult linguistic initiations, mean: G1: 50.8 G2: 1.3 G1/BL: P < 0.001 G2/BL: P = NS G1/G2: P < 0.00003 Adult responses, mean %: G1: 96.7 G2: 76.94 G1/BL: P < 0.01 G2/BL: P = NS G1/G2: P < 0.003 Adult-to-child initiations with opportunity for child response: G1: 44.7 G2: 59.5 G1/BL: P < 0.05 G2/BL: P = NS G1/G2: P = NS Child response, mean %: G1: 66.80 G2: 58.40 G1/BL: P < 0.03 G2/BL: P = NS G1/G2: P < 0.01 Adult-to-child initiations with no opportunity for child response, mean: G1: 13.3 G2: 21.1 G1/BL: P < 0.005 G2/BL: P = NS G1/G2: P = 0.0495
| | | Adult response, mean %: G1: 76.30 Adult-to-child initiations with opportunity for child response: G1: 43.4 G2: 51 Child response, mean %: G1: 51.30 G2: 59.60 Adult-to-child initiations with opportunity for child response, 6 weeks before intervention, mean: G1: 48.5 Child response, mean %: G1: 53.30 Adult-to-child initiations with no opportunity for child response: G1: 24.9 G2: 18.9 Adult-to-child initiations with no opportunity for child response, mean: G1: 23.1 | Harms: NR Modifiers: NR

Chalfant et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Chalfant et al., 2007 Country: Australia Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: RCT | Intervention: CBT based on “cool kids” (Lyneham, Abbott, Wignall, & Rapee, 2003) consisted of recognition of anxious feelings and reactions to anxiety, cognitive restructuring strategies, coping self-talk, exposure to feared stimuli, and relapse prevention; 2-hr weekly sessions for 9 weeks, and three monthly booster sessions totaling 12 sessions Groups: G1: CBT G2: Wait-list control Provider:; - Clinical psychologist; Assessment: Multi-modal and multi-person assessment Self report: RCMAS, SCAS, CATS Parent-report: SCAS, SDQ Teacher report: SDQ Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 32 G2: 19 N at follow-up: G1: 28 G2: 19 | Inclusion criteria:; - Met criteria for an anxiety Disorder beyond their ASD symptoms.; - Children with frequent, irrational fears and avoidant behaviors; Exclusion criteria:; - Intellectual delay; - Physical disability; - Currently taking anti-anxiety or anti-depressant medication; - Those presenting with marked externalizing difficulties (e.g. Conduct Disorder or Oppositional Defiant Disorder) or whose parents were experiencing acute marital breakdown; Age, mean/years ± SD: G1 and G2 combined: 10.8 ± 1.35 Range: 8–13 years Mental age: NR Gender: G1 and G2 combined M, n (%): 35 (74) F, n (%): 12 (26) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In Study (method): Independent diagnosis; confirmed during baseline Referral (method): Community health centers, mental health professionals, medical practitioners, and parents | Commonly occurring comoribidities: Child Report: Children’s Automatic Thoughts Scale (internalizing), mean ± SD: G1: 43.82 ± 22.91 G2: 54.58 ± 14.8 Revised Children’s Manifest Anxiety Scale, mean ± SD: G1: 15.86 ± 3.33 G2: 17.58 ± 4.10 Spence Children’s Anxiety Scale, mean ± SD: G1: 43.57 ± 12.74 G2: 42.26 ± 8.53 Children’s Automatic Thoughts Scale (hostile intent), mean ± SD: G1: 14.75 ± 8.61 G2: 11.21 ± 5.67 Parent Report: Spence Children’s Anxiety Scale – Parent report, mean ± SD: G1: 44.96 ± 13.7 G2: 46.79 ± 10.95 Strengths and difficulties questionnaire – Parent report (emotional), mean ± SD: G1: 7.25 ± 1.88 G2: 7.37 ± 2.48 Strengths and difficulties questionnaire – Parent report (externalizing), mean ± SD: G1: 6.96 ± 4.29 G2: 5.95 ± 5.23 | Commonly occurring comorbidities: Child Report: Children’s Automatic Thoughts Scale (internalizing), mean ± SD: G1: 10.39 ± 5.56 G2: 51 ± 11.87 Revised Children’s Manifest Anxiety Scale, mean ± SD: G1: 4.93 ± 2.55 G2: 16.74 ± 4.63 Spence Children’s Anxiety Scale, mean ± SD: G1: 13.79 ± 10.96 G2: 41.37 ± 9.09 Children’s Automatic Thoughts Scale (hostile intent), mean ± SD: G1: 9.54 ± 5.64 G2: 11.37 ± 5.25 Parent Report: Spence Children’s Anxiety Scale – Parent report, mean ± SD: G1: 13.96 ± 5.11 G2: 44.16 ± 9.04 Strengths and difficulties questionnaire – Parent report (emotional), mean ± SD: G1: 2.75 ± 1.38 G2: 8.21 ± 1.03
Author: Chalfant et al., 2007 Country: Australia Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: RCT | | Diagnostic tool / method: Diagnosed by pediatrician, Psychiatrists or psychologists Diagnostic category, n (%): G1 and G2 combined High Functioning Autistic Disorder: 13 (28) Asperger’s Disorder: 34 (72) Other characteristics, n (%): G1 and G2 combined SAD: 8 (17) GAD: 14 (30) SP: 20 (43) SpP: 3 (6) PD: 2 (4) ADHD: 13 (28) G1, %: SAD: 18 GAD: 32 SP: 43 SpP: 4 PD: 4 G2, %: SAD: 16 GAD: 26 SP: 42 SpP: 11 PD: 5 | Teacher report: Strengths and difficulties questionnaire – Teacher report (emotional), mean ± SD: G1: 5.61± 1.99 G2: 6.32 ± 2.14 Strengths and difficulties questionnaire – Teacher report (externalizing), mean ± SD: G1: 5.79 ± 4.52 G2: 4.79 ± 4.65 Number of anxiety disorder diagnoses between G1 & G2 at pre- treatment: G1 vs. G2 NS, P>0.05 No significant difference elicited between G1 & G2 for any of the child/parent or teacher reported measures (P > 0.05) | Strengths and difficulties questionnaire – Parent report (externalizing), mean ± SD: G1: 3.82 ± 3.12 G2: 6.32 ± 4.92 Teacher report: Strengths and difficulties questionnaire – Teacher report (emotional), mean ± SD: G1: 2.39 ± 1.45 G2: 6.89 ± 1.82 Strengths and difficulties questionnaire – Teacher report (externalizing), mean ± SD: G1: 2.75 ± 2.32 G2: 4.89 ± 4.58 Comparisons: Number of anxiety disorder diagnoses between G1 & G2 at pre-post treatment: Time effect: F=73.66 P < 0.001 Time × group: F=63.79 P < 0.001 Within G1 Pre vs. post F=10.41 P < 0.01 Within G2 Pre vs. Post P > 0.05 Within Post trt G1 vs. G2 t=5.07 P < 0.01
Author: Chalfant et al., 2007 Country: Australia Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: RCT | | | | Child report measures: CATS Internalising: Time effect: F=37.58 P < 0.005 Time × group: F=24.45 P < 0.005 Within G1 Pre vs. post t=7.85 P < 0.01 Within G2 Pre vs. Post ns P > 0.05 Within Post trt G1 vs. G2 t=15.78 P < 0.01 RCMAS: Time effect: F=96.89, P < 0.005 Time × group: F=71.15 P < 0.005 Within G1 Pre vs. post t=14.88 P < 0.01 Within G2 Pre vs. Post Ns, P>0.05 Within Post trt G1 vs. G2: t=11.25 P < 0.01 SCAS: Time effect: F=58.13 P < 0.005
Author: Chalfant et al., 2007 Country: Australia Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: RCT | | | | Time × group: F=51.54 P < 0.005 Within G1 Pre vs. post t=10.91 P < 0.01 Within G2 Pre vs. Post NS P > 0.05 Within Post trt G1 vs. G2 t=9.05 P < 0.01 CATS-Hostile: NS Parent-Report measures comparison: SCAS-P: Time effect: F=74.26 P < 0.005 Time × group: F=52.84 P < 0.005 Within G1 Pre vs. post t=11.48 P < 0.01 Within Post trt G1 vs. G2 t=14.61 P < 0.01 SDQ-Emotional: Time effect: F=25.48 P < 0.005 Time × group: F=54.34 P < 0.005 Within G1 Pre vs. post t=10.28 P < 0.01
Author: Chalfant et al., 2007 Country: Australia Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: RCT | | | | Within Post tx G1 vs. G2 t=14.69 P < 0.01 SDQ-Externalizing: Time effect: F=10.06 P < 0.005 Time × group: F=16.11 P < 0.005 Within G1 Pre vs. post t=5.23 P < 0.01 Within Post trt G1 vs. G2 NS Teacher-rated measures: SDQ Emotional: Time effect: F=13.85 P < 0.005 Time × group: F=28.70 P < 0.005 Within G1 Pre vs. post t=8.25 P < 0.01 Within Post trt G1 vs. G2 t=9.42 P < 0.01 SDQ-Externalizing: Time effect: F=10.86 P < 0.005 Time × group: F=12.48 P < 0.005
Author: Chalfant et al., 2007 Country: Australia Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: RCT | | | | Within G1 Pre vs. post t=4.997 P < 0.01 Within Post trt G1 vs. G2 NS Within G2 (pre vs. post treatment) none of the parent and teacher rated measures were significant (P > 0.05) Harms: NR Modifiers: NR

Coben et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Coben et al., 2007 Country: US Practice setting: Private practice Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: Neurorehabilitation and Neuropsychological services (2) Design: Non randomized controlled trial | Intervention: Assessment-guided neurofeedback for at least 20 sessions Assessments: Diagnostic interview with parents to ascertain core behavioral, cognitive, and social/emotional issues of concern Before and after treatment: ATEC, GADS, GARS, BRIEF, PIC-2, Quantitative EEG analysis, and infrared imaging Groups: G1: intervention G2: waitlist group Provider: NR Measure of treatment fidelity reported: No Co-interventions held stable during treatment: Yes (no new treatments undertaken by study participants) Concomitant therapies, n (%): One medication: G1: 8 (22) G2: 2 (12) Two medications: G1: 5 (14) G2: 1 (8) Three medications: G1: 2 (5) G2: 1 (8) N at enrollment: G1: 38 G2: 12 N at follow-up: G1: 37 G2: 12 | Inclusion criteria:; - Diagnosed ASD; Exclusion criteria:; - See inclusion criteria; Age, years (range): G1: 8.92 (3.92–14.66) G2: 8.19 (5.83–10.92) Mental age: NR Gender, n (%): Male: G1: 31 (84) G2: 10 (83) Female: G1: 6 (16) G2: 2 (17) Race/ethnicity, n (%): White: G1: 36 (97) G2: 12 (100) Asian: G1: 1 (3) G2: 0 SES: Maternal education: NR Household income: NR Diagnostic approach: In Study/Referral Diagnostic tool/method: NR Diagnostic category, n (%): Autism: G1: 7 (18.9) G2: NR PDD-NOS: G1: 21 (56.8) G2: NR Aspergers: G1: 5 (13.5) G2: NR Childhood disintegrative disorder: G1: 4 (10.8) G2: NR Other characteristics, n (%): Right handed: G1: 27 (73) G2: 9 (75) | Overall ratings: ATEC total score, mean: G1: 46.1 GADS ADQ score, mean: G1: 83.852 BRIEF GEC score, mean: G1: 71.700 PIC-2 TOTC score, mean: G1: 71.250 Medical: Neuropsychological testing, mean composite score: Attention: G1: −1.859 Visual perception: G1: −2.483 Executive: G1: −1.818 Language: G1: −1.928 Medical: IR imaging, first session, minimum thermal reading, mean: G1: 93.523 IR imaging, first session, range of thermal degrees: G1: 4.032 | Overall ratings: ATEC total score, mean: G1: 27.733 G1/BL: P < 0.000 GADS ADQ score, mean: G1: 72.519 G1/BL: P < 0.001 BRIEF GEC score, mean: G1: 64.767 G1/BL: P < 0.003 PIC-2 TOTC score, mean: G1: 64.250 G1/BL: P < 0.006 Medical: Neuropsychological testing, mean composite score: Attention: G1: −0.571 G1/BL: P < 0.000 Visual perception: G1: −1.584 G1/BL: P < 0.000 Executive: G1: −0.783 G1/BL: P < 0.001 Language: G1: −0.798 G1/BL: P = 0.000 Medical: IR imaging, 20th session, minimum thermal reading, mean: G1: 94.368 G1/BL: P = 0.043 IR imaging, 20th session, range of thermal degrees: G1: 3.574 G1/BL: P = 0.050 Parent judgment of treatment outcome, n (%): Improved symptoms: G1: 33 (89) G2: 2 (17)
| | Left handed: G1: 5 (14) G2: 2 (17) Mixed handedness: G1: 5 (14) G2: 1 (8) ATEC score, mean (range): G1: 45.16 (12–100) G2: 45.23 (26–72) | | No change: G1: 4 (11) G2: 10 (83) G1/G2: P = 0.000 Harms: No reports of worsening symptoms (benefit to harm ratio 89:1) Modifiers: Ruled out confounding for baseline severity of ASD, age, and number of medications.

Comments:

* The numbers in this paper are extremely difficult to read; data extraction may be incorrect.

Dosman et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Dosman et al., 2007 Country: Canada Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: Prospective case series | Intervention: Oral iron supplement: 6 mg elemental iron/kg/day; if it was anticipated that oral preparations would not be accepted by the child, iron Sprinkles (Supple-Forte) were offered: two 30 mg sachets/day Average duration of treatment was 7.2 weeks (range 4–8 weeks) Assessments: Prior to baseline and at post-treatment, parents completed SDSC (26 items), Periodic Leg Movements during Sleep scale (6 items), 3 day Food Record, Nutritional Supplement Log, and irritability measure (developed by authors based on CGIS) Baseline and post treatment growth measures and blood samples were taken for serum ferritin and transferrin receptor, mean corpuscular volume, hemoglobin, albumin, and vitamin B_12_ in the child Groups: G1: iron intervention Ga: preschool age (less than 6 years old) G1a: school age (6 or more years old) Gi: ferritin < 10 μg posttreatment Gii: ferritin > 10 μg posttreatment Gc: children on SSRI or stimulant medication (and completed SDSC) Co-interventions held stable during treatment: NR Frequency of contact during study: NR | Inclusion criteria:; - Child had had ferritin measured previously as part of routine diagnostic assessment from autism at The Hospital for Sick Children’s tertiary level Child Development Centre; Exclusion criteria:; - Currently receiving iron supplement; Age, years (range): G1: 6.5 (2.67–10.75) Mental age: NR Gender, n: Male: 27/33 Female: 6/33 Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: NR Diagnostic tool/method: ADI-R, ADOS, and clinical evaluation Diagnostic category: NR | Commonly occurring co-morbidities: CGIS irritability, mean: G1: 1.19 (n=32) Medical: SDSC restless sleep score (1–5), mean ± SD: G1: 3.7 ± 1.450 (n=32) G1c: 3.4 ± 1.60 SDSC restless sleep, abnormal, %: G1: 77 SDSC delayed sleep onset, n (%): G1: 14/31 (44) G1c: 5/8 (62.5) Periodic Leg Movements during Sleep, children with mean score > 0.33, n (%): G1: 14/32 (44) Dietary iron intake, median mg/day (range): G1a: 13.7 (4–39) G1b: 17.85 (7–43) Insufficient dietary iron intake, %: G1a: 69 G1b: 35 Ferritin, mean μg/L (range): G1: 15.72 (4.2–39.0) Low ferritin (< 10 μg/L), n: G1a: 6 G1b: 2 G1a/G1b: P = NS Albumin below normal levels, n: G1: 0/32 Vitamin B_12_ below normal levels, n: G1: 0/32 | Commonly occurring comorbidities: : CGIS irritability, mean: G1: 1.0 (n=32) G1/BL: P = NS Medical: SDSC restless sleep score, showing improvement, n (%): G1: 7/24 (29) G1/BL: P = 0.04 SDSC delayed sleep onset, n (%): G1: 11/31 (35) G1/BL: P = NS Periodic Leg Movements during Sleep, children with mean score > 0.33, n (%): G1: 12/32 (38) G1/BL: P = NS Dietary iron intake, median mg/day (range): G1: NR G1/BL: P = 0.32 Ferritin, mean μg/L (range): G1: 28.8 (6.6–103) G1/BL: P < 0.001 Low ferritin (<10 μg/L), n: G1a: 3 G1b: 0 G1/BL: P = NS Albumin, below normal levels n: G1: NR Vitamin B_12_, below normal levels, n: G1: 2/32
| Concomitant therapies: NR N at enrollment: G1: 43 G1a: 16 G1ai: NR G1aii: NR G1b: 17 G1c: 8 N at follow-up: G1: 33 G1a: 16 G1ai: NR G1aii: NR G1b: 17 G1c: NR | Other characteristics, n (%): Any gastrointestinal symptom: 28/43 (65) Constipation: 14/43 (33) Loose stools: 14/43 (33) Failure to thrive, abdominal distension and pain, excessive gas: 16/43 (37) Seizures: 9/43 (21) Gluten and/or casein-free diet: 11/43 (26) SSRI: 7/43 (16) Melatonin: 3/43 (7) Antiepileptic: 4/43 (9) Stimulant: 2/43 (5) Antihistamine: 3/43 (7) Vitamin supplement: 14/43 (33) Nutritional supplement: 7/43 (16) Ferritin < 50 μg/L: 43/43 (100) Iron supplementation, n: Iron suspension: 23/33 Sprinkles: 10/33 Gastrointestinal symptoms, n (%): 23/33 (76) Number of gastrointenstinal symptoms, mean: G1: 1.9 G1ai: 3.3 G1aii: 0.8 | Mean corpuscular volume, fl ± SD: G1: 80.8 ± 3.79 Children with mean corpuscular volume < 80 fl, n (%): G1: 14/33 (42) Hemoglobin, mean gm/L ± SD: G1: 125.6 ± 7.00 Children with serum concentration of hemoglobin < 110 gm/L (2–4 year olds) or < 120 gm/L (5–10 year olds), %: G1: 3/33 (9) Transferrin receptor, mean μg/mL ± SD (range): G1: 5.43 ± 1.49 (3.46–9.94) (n=25) Children with serum transferrin receptor > 8.3 μg/mL, n (%): G1: 1/25 (4) | Mean corpuscular volume, mean change fl (SE): G1: 1.02 (0.30) G1/BL: P = 0.002 Children with mean corpuscular volume < 80 fl, n (%): G1: 8/33 (24) Hemoglobin, mean change gm/L (SE): G1: 2.42 (1.06) G1/BL: P = 0.029 Children with serum concentration of hemoglobin < 110 gm/L (2–4 year olds) or < 120 gm/L (5–10 year olds), %: G1: 1/33 (3) Transferrin receptor, mean change μg/mL (SE): G1: 0.06 (0.24) G1/BL: P = NS Children with serum transferrin receptor > 8.3 μg/mL, n (%): G1: 1/25 (4) Harms: Withdrew due to AEs, n: 2/43 Treatment-related AEs, n (%): Any symptom: 13/33 (39) Gastrointestinal symptom: 9/33 (27) Constipation: 4/33 (12) Loose stools: 6/33 (18) Abdominal pain: 1/33 (3) Decreased appetite: 1/33 (3)
| | | | Stained teeth: 2/33 (6) Increased night waking: 1/33 (3) Decreased sleep: 1/33 (3) Decreased attention, aggression: 1/33 (3) Enuresis: 1/33 (3) Modifiers: No correlation between ferritin and ADI or ADOS scores except for children aged 4–8 (inverse relationship between ferritin and ADOS-communication domain; P = 0.009) No consistent relationship found between dietary iron intake and ferritin

Eikeseth et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Eikeseth et al., 2002 Eikeseth et al., 2007† Country: Norway Practice setting: Academic Intervention setting: School Enrollment period: November 1995 to November 1998 Funding: NIH† Author industry relationship disclosures: NR Design: Non randomized controlled trial | Intervention: Behavioral treatment: Lovaas treatment excluding aversive contingencies; progression from simple to complex tasks such as imitating verbal and nonverbal behavior, labeling objects, identifying actions, and abstract concepts. Progression to answering questions, conversing and making friends with peers. Also emphasized play and social skills. Based on operant conditioning principles such as shaping, chaining, discrimination training, and contingency management. Progressed from discrete trial to generalizing skills. Eclectic treatment: best practices, including TEACCH, sensory-motor therapies, and ABA Treatment hours, mean ± SD (range): G1: 28 ± 5.76 (20–35) G2: 29.08 ± 8.05 (20–41) Assessments: ADI-R administered by independent child clinical psychologist prior to study Weekly, 2-hour meetings with child, primary caregiver, therapists, supervisor, and director; treatment program was modified based on data collected during the preceding week | Inclusion criteria:; - Age 4–7 years at intake; - Diagnosed with autism according to ADI-R administered by child clinical psychologist and clinical interview; - Diagnosis established less than 6 months prior to study entrance for all participants; - Deviation IQ of 50 or above on WPPSI-R or ratio IQ of 50 or above on BSID-R; - No major medical conditions; Exclusion criteria:; - See inclusion criteria; Age, months ± SD: G1: 66.31 ± 11.31 G2: 65 ± 10.95 Mental age: See IQ scores in baseline measures Gender, n (%): Male: G1: 8 (62) G2: 11 (92) Female: G1: 5 (38) G2: 1 (8) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In Study Diagnostic tool/method: ADI-R and clinical interview conducted by clinical psychologist independent of the investigation Diagnostic category, n (%): Autism: 25 (100) Other characteristics: NR | Educational/cognitive: IQ, mean ± SD: G1: 61.92 ± 11.31 G2: 65.17 ± 14.97 PIQ, mean ± SD: G1: 77.54 ± 30.21 G2: 81.83 ± 21.05 Communication/language: Language status, mean ± SD: Comprehension: G1: 49.03 ± 16.42 G2: 50.38 ± 15.46 Expressive: G1: 45.12 ± 13.44 G2: 51.24 ± 19.24 Total: G1: 51.83 ± 17.42 G2: 60.00 ± 24.22 VABS communication score, mean ± SD: G1: 58.23 ± 9.21 G2: 63.17 ± 16.11 Adaptive behavior: VABS daily living score, mean ± SD: G1: 56.92 ± 9.8 G2: 57.00 ± 15.92 VABS composite score, mean ± SD: G1: 55.77 ± 8.96 G2: 60.00 ± 13.2 Social skills:^*^ VABS socialization score, mean ± SD: G1: 59.92 ± 7.19 G2: 62.17 ± 10.32 | Educational/cognitive: IQ, mean ± SD: 1 year: G1: 79.08 ± 18.09 G2: 69.5 ± 18.38 G1/G2: P < 0.01 8 years:† G1: 86.9 ± 25 G2: 71.9 ± 28.4 G1/G2: P < 0.05 PIQ, 1 year, mean ± SD: G1: 95 ± 16.91 G2: 90.17 ± 19.97 Communication/language: Language status, 1 year, mean ± SD: Comprehension: G1: 58.47 ± 17.11 G2: 47.55 ± 17.25 G1/G2: P < 0.05 Expressive: G1: 67.39 ± 17.81 G2: 49 ± 18.69 G1/G2: P < 0.05 Total: G1: 76.85 ± 26.67 G2: 61.58 ± 24.34 G1/G2: P < 0.05 VABS communication score, mean ± SD: 1 year: G1: 73.93 ± 16.55 G2: 61.58 ± 13.37 G1/G2: P < 0.01 8 years:† G1: 78.5 ± 22.3 G2: 56 ± 16.3 G1/G2: P < 0.01 Adaptive behavior: VABS daily living score, mean ± SD: 1 year: G1: 66.15 ± 16.55 G2: 62.5 ± 10.97
| Child assessed at intake and 1 year after treatment began (follow-up conducted by licensed psychologist or examiner with Master’s in Special Education and license to administer tests); standardized tests of intelligence (WPPSI-R or WISC-R), visual-spatial skills (Merrill-Palmer Scale of Mental Tests), language (Reynell Developmental Language Scales), and adaptive functioning (VABS) Groups: G1: behavioral G2: eclectic Provider:; - One or more aides; - Special education teacher; Measure of treatment fidelity reported: No Co-interventions held stable during treatment: Yes Concomitant therapies: NR N at enrollment: G1: 13 G2: 12 N at follow-up: G1: 13 G2: 12 | | | 8 years:† G1: 66.1 ± 18.1 G2: 50.4 ± 20.2 G1/G2: P < 0.05 VABS composite score, mean ± SD: 1 year: G1: 67 ± 16.3 G2: 60.17 ± 11.69 G1/G2: P < 0.05 8 years:† G1: 67.9 ± 17.1 G2: 49.5 ± 13 G1/G2: P < 0.01 Social Skills: VABS socializetion score, mean ± SD: 1 year: G1: 69.92 ± 17.26 G2: 70.67 ± 13.66 8 years:† G1: 72.2 ± 14.4 G2: 58.1 ± 9.6 G1/G2: P < 0.01 VABS maladaptive behavior score, mean ± SD: 1 year: G1: 4.29 ± 2.89 G2: 7.25 ± 2.99 G1/G2: P < 0.05 8 years:† G1: 6.3 ± 4.1 G2: 11 ± 5.8 G1/G2: P < 0.05 Problem behavior: Achenbach Child Behavior Checklist, 8 years, mean ± SD:† Withdrawn: G1: 59.4 ± 6.3 G2: 61.4 ± 5.3 Somatic: G1: 55 ± 7 G2: 58 ± 9.6
| | | | Anxious/depresssed: G1: 57.8 ± 6.1 G2: 57.1 ± 7.1 Social: G1: 62.3 ± 6.3 G2: 67.2 ± 4.9 G1/G2: P < 0.05 Thought: G1: 68.1 ± 9.6 G2: 68.5 ± 7 Attention: G1: 59 ± 5.4 G2: 62.1 ± 6.1 Delinquent: G1: 56 ± 5.2 G2: 59 ± 3.8 Aggressive: G1: 57.3 ± 4.5 G2: 63.7 ± 4.6 G1/G2: P < 0.01 Harms: NR Modifiers: G1: intake IQ correlated with change in language at one year follow-up (r = 0.59; P < 0.05) intake PIQ correlated with change in PIQ at one-year follow-up (r = −0.84; P < 0.01); intake VABS correlated with change in PIQ at one year follow-up (r = − 0.60; P < 0.05).
| | | | G2: age at intake correlated with change in VABS at one year follow-up (r = −0.65; P < 0.05) and change in VABS communication at eight-year follow-up (r = −0.64; P < 0.05);† intake PIQ correlated with change in IQ at one-year follow-up (r = 0.67; P < 0.05), intake VABS daily living and socialization correlated with change in IQ at eight-year follow-up (r = 0.58; P < 0.05),† VABS composite correlated with change in IQ at eight-year follow- up (r = 0.63; P < 0.05).†

Comments:

* VABS maladaptive not given at baseline because it is normed for children 5 years and older.

Gabriels et al., 2001 and 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Gabriels et al., 2001 and 2007 Country: US Practice setting: Academic Intervention setting: home, school, clinic Enrollment period: NR Funding: Agency/NR Author industry relationship disclosures: NR Design: 2001: Retrospective cohort with some prospective data collection 2007: Prospective case series | Intervention: Combination of variety of treatments (e.g., TEACCH, LEAP or DENVER Model) from community providers over a period of 37 months (1^st^ follow up) or 5 years (2^nd^ follow-up) Assessments: 2001: Assessment records were requested, photocopied, placed in the participant’s file, and reviewed upon completion of testing Participants, with parent(s) present, completed testing in up to 3 sessions; MSEL, PLS- III, & during 3^rd^ session, subtests of Woodcock- Johnson Revised Tests of Achievement and ADOS- G Participants were evaluated by a team of study evaluators, consisting of a psychology postdoctoral fellow, a psychology intern, and a speech-language clinical fellow 2007: Leiter International Performance Scale- Revised (LIPS-R), VABS, CCIF, Expressive One- Word Picture Vocabulary Test-Revised (EOWPVT- R), and PPVT-III | Inclusion criteria:; - Current diagnosis of autistic disorder or PDD- NOS; - At least 22 months post- diagnosis; - Available standardized intellectual and/or language functioning scores at time of diagnosis; Exclusion criteria:; - History of traumatic brain injury; - History of seizure disorder, fragile X, or other known genetic or biologic problems; No additional psychiatric disorders; Age at diagnosis, mean months ± SD (range): 30.6 ± 7.27 (20–47) Age at 1^st^ follow-up, mean months ± SD (range): 68.7 ± 10.11 (44– 88) G1a: 69±9.3 G1b: 68±11.5 Mean age at 2^nd^ follow- up: 11.42 Age at 2^nd^ follow-up, mean years ± SD: G1c: 10.69 ± 0.72 G1d: 10.88 ± 0.74 Mental age: NR Gender, n: M: 12 (10 at 2^nd^ follow-up) F: 5 (4 at 2^nd^ follow-up) Race/ethnicity, n: Anglo: 14 (at 1^st^ and 2^nd^ follow-up) African American/Native American: 1 Hispanic: 1 Asian: 1 (1 non-Anglo ethnicity at 2^nd^ follow-up) SES: Maternal education: NR | Educational/cognitive/academic attainment: Cognitive quotient at diagnosis (n=16), mean ± SD (range): 57.81 ± 25.88 (25.00–128.00) G1a: 68.50 ± 30.78 G1b: 47.12 ± 15.06 Communication/language: Language quotient at diagnosis (n=15), mean ± SD (range): 42.46 ± 16.11 (5.00– 72.00) G1a (n=7): 47.42 ± 12.48 G1b: 28.12 ± 18.43 | Social skills: VABS Socialization at 1^st^ follow-up, mean ± SD: G1c: 64.75 ± 16.97 G1d: 38.50 ± 11.54 VABS Socialization at 2^nd^ follow-up, mean ± SD: G1c: 84.38 ± 10.97 G1d: 39.33 ± 11.98 VABS Socialization age equivalent at 2^nd^ follow-up, mean years ± SD: G1c: 5.54 ± 1.72 G1d: 1.78 ± 0.86 Communication/language: Language quotient at 1^st^ follow-up, mean ± SD (range): 57.64 ± 31.96 (16.00– 119.00) G1a: 82.11 ± 22.23 (significant increase compared with baseline, P = 0.01) G1b: 30.12 ± 11.61 EOWPT standard score at 2^nd^ follow-up, mean± SD: G1c: 112.13 ± 9.09 G1d: 59.83 ± 11.84 (t(12) = 9.38, P < 0.001, G1c vs. G1d)
| Groups: G1a: children with developmental IQ ≥64 at 1^st^ follow-up G1b: children with developmental IQ ≤ 48 at 1^st^ follow-up G1c: children with nonverbal intelligence (NVIQ) ≥ 97 at 2^nd^ follow-up G1d: children with NVIQ score ≤ 56 at 2^nd^ follow-up Provider: Community providers; details not reported Measure of treatment fidelity reported: No Co-interventions held stable during treatment: Yes Therapies at 1^st^ follow-up (parent report data), n: Structured home program: G1a: 5 G1b: 5 Private speech therapy: G1a: 9 G1b: 7 Private occupational therapy: G1a: 5 G1b: 5 Current public special education classroom: G1a: 5 G1b: 6 Current public integrated classroom with special education services: G1a: 3 G1b: 2 Current public integrated classroom (no special education services): G1a: 1 G1b: 0 Social tutoring: G1a: 1 G1b: 0 | Household income: NR Hollingshead at 1^st^ follow- up, mean ± SD (range): 56.25 ± 10.68 (27.00– 66.00) G1a: 54.88 ±12.6040 G1b: 57.75 ± 8.61 Hollingshead at 2^nd^ follow- up, mean ± SD: G1c: 58.63 ± 4.17 G1d: 56.00 ± 8.07 Diagnostic approach: In Study Diagnostic tool/method: Initial diagnosis by clinic multidisciplinary team including a psychiatrist or psychologist with extensive experience in diagnosing early childhood autism; children re-diagnosed at time of first follow-up study using ADOS-G Diagnostic category at 1^st^ follow-up, n: Autism: 15 PDD-NOS: 2 Diagnostic category at 2^nd^ follow-up, n: Autism: 12 PDD-NOS: 2 Other characteristics: Age began treatment, mean months ± SD: G1a: 33 ± 8.7 G1b: 31 ± 5.9 Total hours of treatment per month at 1^st^ follow-up, mean ± SD: G1a: 103.22 ± 66.33 G1b: 76.25 ± 48.10 Mean school-based treatment hours/week ± SD at 2^nd^ follow-up: G1c: 31.2 ± 3.8 G1d: 33.8 ± 2.1 | | PPVT-III standard score at 2^nd^ follow-up, mean ± SD: G1c: 101.50 ± 12.62 G1d: 46.83 ± 16.74 (t(12) = 6.99, P < 0.001, G1c vs. G1d) VABS Communication score at 1^st^ follow- up, mean ± SD: G1c: 92.63 ± 13.16 G1d: 37.17 ± 19.94 VABS Communication score at 2^nd^ follow-up, mean ± SD: G1c: 115.50 ± 7.93 G1d: 49.83 ± 27.12 VABS Communication age-equivalent at 2^nd^ follow-up, mean years ± SD: G1c: 8.49 ± 2.56 G1d: 2.46 ± 1.62 Adaptive behavior: Adaptive quotient at 1^st^ follow-up, mean ± SD G1a: 80.77 ± 14.28 G1b: 37.75 ± 16.26 P ≥ 0.01
| Vision therapy: G1a: 2 G1b: 1 Music therapy: G1a: 1^*^ G1b: 1 Cranio-sacral: G1a: 1^*^ G1b: 0 Kinesiology: G1a: 1^*^ G1b: 0 Homeopathy: G1a: 1^*^ G1b: 0 Horseback riding therapy: G1a: 1^*^ G1b: 0 Sensory learning therapy: G1a: 1^*^ G1b: 0 *same child received all these therapies; additional details on treatment overlap not reported School-based therapies at 2^nd^ follow-up (parent report data), n: Special education class only: G1c: 0 G1d: 1 Integrated class (no special education): G1c: 7 G1d: 0 Mixed (special education and integrated classes): G1c: 1 G1d: 5 Speech therapy: G1c: 4 G1d: 5 Occupational therapy: G1c: 2 G1d: 4 1:1 paraprofessional: G1c: 3 G1d: 3 Music therapy: G1c: 0 G1d: 1 Social skills group: G1c: 3 G1d: 1 | Mean private treatment hours/week ± SD at 2^nd^ follow-up: G1c: 1.7 ± 2.4 G1d: 1.8 ± 3.2 | | VABS standard composite score at 2^nd^ follow-up, mean ± SD: G1c: 67.38 ± 16.24 G1d: 27.67 ± 9.35 (F(1,12) = 33.67, P < 0.001, G1c vs. G1d) VABS raw composite, 1^st^ follow-up, mean ± SD: G1c: 238.25 ± 46.89 G1d: 127.00 ± 50.32 (P < 0.001, G1c vs. G1d) VABS raw composite, 2^nd^ follow-up, mean ± SD: G1c: 300.75 ± 45.30 G1d: 128.00 ± 34.19 (P < 0.001, G1c vs. G1d) VABS Daily Living at 1^st^ follow-up, mean ± SD: G1c: 80.13 ± 20.21 G1d: 51.33 ± 21.18 VABS Daily Living at 2^nd^ follow-up, mean ± SD: G1c: 109.25 ± 37.91 G1d: 63.83 ± 24.31 VABS Daily Living age equivalent at 2^nd^ follow-up, mean/years ± SD G1c: 7.77 ± 2.65 G1d: 3.35 ± 1.46
| Private therapies at 2^nd^ follow-up (parent report data), n: Home trainer: G1c: 1 G1d: 1 Speech therapy: G1c: 0 G1d: 2 Occupational therapy: G1c: 0 G1d: 1 Social tutoring/group: G1c: 2 G1d: 1 Family therapy: G1c: 2 G1d: 0 Parent support group: G1c: 1 G1d: 1 Respite care: G1c: 0 G1d: 5 N at enrollment: 17 N at 1^st^ follow-up (at least 22 months post- diagnosis): 17 G1a: 9 G1b: 8 N at 2^nd^ follow-up: 14 G1c: 8 G1d: 6 | | | Educational/cognitive/academic attainment: Cognitive quotient at 1^st^ follow-up, mean ± SD (range): 62.94 ± 30.79 (25.00– 126.00) G1a: 87.11 ± 20.50 G1b: 35.75 ± 9.51 (G1b significant decrease compared with baseline, p=.03) G1a vs. G1b: P < 0.01 Academic quotient at 1^st^ follow-up, mean ± SD: G1a: 113.11 ± 30.58 G1b: 66.38 ± 18.86 P ≤ 0.01 Non-Verbal IQ at 2^nd^ follow-up, mean ± SD G1c: 110.13 ± 18.47 G1d: 43.17 ± 10.59 Non-Verbal IQ > adaptive ability G1c: t(14) = 4.92, P < 0.001; G1d: t(10) = 2.69, P = 0.02 Within G1c: Age equivalent score for Socialization < communication subscale score (mean diff = 2.86, P = 0.006)
| | | | Within G1d: Daily Living age equivalent score > communication subscale (mean diff = 0.89, P = 0.004) Harms: NR Modifiers: Correlations between the number and intensity of individual, group, and total treatment hours and outcomes at 1^st^ follow-up were all nonsignificant (P > 0.05) Initial development IQ scores correlated significantly with 1^st^ follow-up developmental IQ scores (r = 0.70, P < 0.01), language scores (r= 0.69, P < 0.01) academic scores (r = 0.74, P < 0.01) and adaptive functioning (r =0.57, P = 0.02) Initial language scores were not significantly correlated with 1^st^ follow-up outcome measures (P > 0.05) Finance and business strains significantly greater in G1b vs. G1a (F (1,14) = 6.27, P = 0.025)
| | | | Trend toward significant difference (P = 0.06) between G1a and G1b regarding extended family social support, mean ± SD: G1a: 9.22 ± 3.30) G1b: 11.62 ± 0.52 Change in developmental IQ over time: Significant interaction overall :F (1,15) = 17.26, P < 0.01 G1a showed significant increase in Developmental IQ from time 1 to 1^st^ follow up (F = 10.46, P = 0.01) G1b showed significant decrease in developmental IQ (F = 7.02, P =0.03) At 1^st^ follow-up, developmental IQ scores significantly different from each other (F = 48.51, P < 0.01)

Gulsrud et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Gulsrud et al., 2007 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NIH Author industry relationship disclosures: NR Design: RCT Note: See related study Wong 2007{#3875}, Kasari 2008{#184}, Kasari 2006{#540}, and Jahromi 2009{#3615} | Intervention: Joint attention or symbolic play intervention, administered during 5–8 week preschool program for 6 hours daily Groups: G1: joint attention G2: symbolic play Provider: NR Assessments: Auditory-visual and auditory probes presented at the beginning, middle and end of the treatment phase; responses: eye gaze, affect, non-verbal gestures, verbalization Measure of treatment fidelity reported: Yes Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 20 G2: 20 N at follow-up: G1: 17 G2: 18 | Inclusion criteria:; - Preschool children from an existing intervention study for preschool children diagnosed with ASD; Exclusion criteria:; - Seizures; - Sensory or physical disorders; - Comorbidity with any other psychological disorder or disease; - Children not given the study’s novel probe activation at the 3 study time points due to scheduling conflicts; Age, months ± SD: G1: 42.65 ± 7.13 G2: 43.11 ± 6.93 Age range (months): Total: 33–54 Mental age, months ± SD: G1: 25.74 ± 9.00 G2: 26.64 ± 7.90 Gender, n: Male: G1: 13 G2: 15 Female: G1: 4 G2: 3 Race/ethnicity, n: White: G1: 12 G2: 14 Minority: G1: 5 G2: 4 SES: Maternal education, n: Completed high school: G1: 0 G2: 2 Some college/technical: G1: 2 G2: 2 College/professional training: G1: 15 G2: 14 | Communication/language: Probe acknowledgement, %: G1: 47 G2: 66 Verbalizations, mean ± SD: G1: 0.30 ± 0.26 G2: 0.67 ± 0.26 Non-verbal gestures, mean ± SD: G1: 0.05 ± 0.06 G2: 0.05 ± 0.06 Ability to engage in coordinated joint looks during probe activation, % G1: 35.7 G2: 50 | Communication/language: Probe acknowledgement, %: G1: 88.2 G2: 55.6 G1/G2: P < 0.05 Probe acknowledgement changes, %: No change: G1: 58.5 G2: 55.6 Increase: G1: 41.2 G2: 16.7 G1/G2: P < 0.05 Verbalizations, mean ± SD: G1: 2.5 ± 0.80 G2: 1.3 ± 0.78 G1/G2: P = NS Non-verbal gestures, mean ± SD: G1: 0.60 ± 0.30 G2: 0.83 ± 0.30 G1/G2: P = NS Ability to engage in coordinated joint looks during probe activation, % G1: 76.5 G2: 38.9 G1/G2: P < 0.05 Harms: NR
| | Household income: NR Diagnostic approach: In Study Diagnostic tool/method: Referral diagnosis validated using ADI-R and ADOS Diagnostic category, n (%): ASD: 35 (100) Other characteristics: Receptive language age, months ± SD: G1: 20.50 ± 8.00 G2: 22.28 ± 9.40 Expressive language age, months ± SD: G1: 20.60 ± 7.20 G2: 22.22 ± 7.60 | | Modifiers: Significant group difference in the duration of coordinated joint looks during probe activation: G1 engaged for longer periods of time across 3 time points compared to G2 (P < 0.05); G2 made no increase or decrease in the duration of coordinated joint looks (only graphically represented)

Gutstein et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Gutstein et al., 2007 Country: US Practice setting: Specialty treatment center Intervention setting: Clinic Enrollment period: January 2000 to May 2003 Funding: NR Author industry relationship disclosures: NR Design: Retrospective case series | Intervention: Relationship Development Intervention (RDI): parents are trained in 6 days of workshops in RDI components to learn how to provide opportunities for their children to respond in more flexible, thoughtful ways to novel, challenging, and increasingly unpredictable settings and problems Assessments: ADOS, ADI-R, flexibility interview (10 items related to child’s ability to adapt to change and transition), and educational placement Groups: G1: RDI training Provider: Parents Duration, median months in RDI (range) : 41.5 (33–79) Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 16 N at follow-up: G1: 16 | Inclusion criteria:; - An interval of at least 30 months between initial and follow-up testing; - Previous diagnosis of autism, Asperger’s syndrome, or PDD-NOS; - Participation in the RDI protocol; - Age at time of RDI initiation 20–96 months; - Pretreatment IQ ≥ 70; Exclusion criteria:; - See inclusion criteria; Age, months ± SD (range): 60.50 ± 20.43 (20–94) Mental age: IQ, mean ± SD (range): 90.50 ± 13.23 (70–118) Gender, n (%): Male: 15 (94) Female: 1 (6) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: NR Diagnostic category, n (%): Autism: 5 (31) Asperger’s syndrome: 7 (44) PDD-NOS: 4 (25) Other characteristics, n (%): Language delays: 8 (50) ADHD: 5 (31) Bipolar disorder: 1 (6) Food allergies: 1 (6) | Overall ratings: ADOS rating, n (%): Autism: 10/12 (83) Autism spectrum: 2/12 (17) Non-autism: 0 Communication/language: ADOS communication score mean ± SD (range): G1: 5.92 ± 1.975 (2–10) ADOS social interaction score mean ± SD (range): G1: 9.58 ± 2.968 (3–13) ADI-R communication + language score, mean (range): G1: 10.6 (7.9–14.3) Age appropriate flexibility, %: Unexpected change to familiar routines: 12.5 Unexpected omission of a routine activity: 18.8 Changes to activities without preparation: 25 Anticipating an event and encountering another: 31.3 Unexpected actions by familiar people: 25 Interruption during a highly favored activity: 6.3 Stopping a task before it is finished: 12.5 Planning for things that might go wrong: 0 | Overall ratings: ADOS rating, n (%): Autism: 0 Autism spectrum: 6/16 (38) Non-autism: 10/16 (63) Communication/language: ADOS communication score, mean ± SD (range): G1: 2.67 ± 0.99 (0–4) G1/BL: P < 0.0001 ADOS social interaction score mean ± SD: (range): G1: 4.17 ± 2.44 (0–9) G1/BL: P < 0.004 ADI-R communication + language score, mean (range): G1: 2.4 (0–5.7) G1/BL: P < 0.0001 Age appropriate flexibility, %: Unexpected change to familiar routines: 81.3 Unexpected omission of a routine activity: 87.5 Changes to activities without preparation: 81.3 Anticipating an event and encountering another: 75 Unexpected actions by familiar people: 75 Interruption during a highly favored activity: 68.8
| | | Adapting when original plans don’t work out: 18.8 Using familiar objects in a novel way: 12.5 Educational Placement, %: Special education: 57.1 Partial mainstream: 28.6 Mainstream with pullout: 7.1 Mainstream: 7.1 Home school: 0 | Stopping a task before it is finished: 68.8 Planning for things that might go wrong: 43.8 Adapting when original plans don’t work out: 75 Using familiar objects in a novel way: 56.3 Educational Placement, %: Special education: 12.5 Partial main-stream: 18.8 Mainstream with pullout: 31.3 Mainstream: 31.3 Home school: 6.3 Harms: NR Modifiers: NR

Howlin et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Howlin et al., 2007 Country: UK Practice setting: Academic Intervention setting: School Enrollment period: NR Funding: NR Author industry relationship disclosures: None Design: RCT, not masked | Intervention: PECS: 2-day workshop (13 hours) for teachers plus 6 half day school- based trainings sessions with expert consultants over 5 months Assessments: ADOS-G, BPVT and EOWPVT administered by researchers in school setting Groups: 18 classrooms (from 15 schools) were randomized into 6 classes per group G1: immediate treatment G2: delayed treatment (recieved PECS 2 terms after study entry) G3: no treatment Provider:; - Teachers trained to teach PECS; - PECS consultants; Measure of treatment fidelity reported: No Measure of observer reliability reported: Yes Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 30 G2: 29 G3: 29 N at follow-up:^*^ G1: 25 G2: 30 G3: 28 | Inclusion criteria:; - Formal clinical autism diagnosis and meet criteria for autism or ASD (ADOS-G); - Little or no functional language; - No evidence of sensory impairment; - Age 4–11 years; - Not using PECS beyond Phase 1; - Each class was required to have a minimum of 3 children who met the above criteria; Exclusion criteria:; - See inclusion criteria; Age, months ± SD (range): G1: 73.1 ± 15.8 (47.3–106.3) G2: 86.6 ± 12.7 (62–113.5) G3: 85.6 ± 13.6 (61–122.1) Mental age: NR Gender, n (%): Male: G1: 21 (81) G2: 27 (90) G3: 25 (89) Female: G1: 5 (19) G2: 3 (10) G3: 3 (11) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral; diagnosis confirmed in study Diagnostic tool/method: ADOS-G Diagnostic category, n (%): Autism: 75 (89) ASD: 9 (11) | Communication/ language: ADOS language impairment score, mean ± SD: G1: 2.7 ± 1.4 G2: 3.4 ± 0.8 G3: 2.5 ± 1.5 G1/G2: P < 0.05 G1/G3: P = NS G2/G3: P < 0.05 Non-verbal mental age equivalent/chronological age × 100, mean ± SD: G1: 25.9 ± 11.4 G2: 22.7 ± 8.2 G3: 27.3 ± 10.2 ADOS total algorithm scores, mean ± SD: G1: 16.4 ± 2.7 G2: 16.9 ± 2.9 G3: 15.3 ± 3.2 | Overall ratings: Rate of initiations, more likely to be in higher initiation rate category, pre-to post-treatment, OR (95% CI): G1+G2/G3: 2.73 (1.22–6.08) Rate of initiations, children moved up one or more categories, pre-to post-treatment, %: G1+G2: 51.8 G3: 25.0 No change: G1+G2: 28.6 G3: 35.7 Moved down one or more categories: G1+G2: 19.6 G3: 39.3 Rate of initiations, more likely to be in higher initiation rate category, post-treatment to 10 month follow- up, OR (95% CI): G1/G3: 1.08 (0.30–3.90) Communication/Language: Rate of speech, pre- to post- treatment, OR (95% CI): G1+G2/G3: 1.10 (0.46–2.62) ADOS-G communication scores, pre- to post-treatment, OR (95% CI): G1+G2/G3: 0.52 (0.24–1.12)
Author: Howlin et al., 2007 Country: UK Practice setting: Academic Intervention setting: School Enrollment period: NR Funding: NR Author industry relationship disclosures: None Design: RCT, not masked | | Other characteristics: NR | | ADOS-G reciprocal socialscores, pre- to post-treatment, OR (95% CI): G1+G2/G3: 0.55 (0.25–1.19) ADOS-G reciprocal social interaction scores, post- treatment to 10 month follow-up, OR (95% CI): G1/G3: 0.28 (0.09–0.89) EOWPVT, pre- to post-treatment, OR (95% CI): G1+G2/G3: 1.01 (0.89–1.15) BPVS, pre- to post-treatment, OR (95% CI): G1+G2/G3: 1.54 (0.52–4.54) Harms: NR Modifiers: NR

Comments:

* For G1, one class withdrew after randomization: the number of children at baseline assessment and post-treatment assessment was 26, and at follow-up assessment was 25; for G2, one girl entered a class a year into the study; for G3, one girl failed to met the criteria for ASD.

Keen et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Keen et al., 2007 Country: Australia Practice setting: Academic Intervention setting: Clinic, Home Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: Case series, prospective Note: For more details on the Stronger Families Project intervention, see Rodger et al., 2004 | Intervention: Stronger Families Project Intervention: A two day parent workshop, followed by 10 sessions of individual home-based early intervention, using a social-pragmatic approach emphasizing functional use of communication skills in natural and semi- structured interactions; 6 week intervention Assessments: Scales of Independent Behavior, CSBS administered by observer in clinic. Parents completed parental stress and component measures. Groups: G1: intervention Provider: NR Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 16 N at follow-up: G1: 16 | Inclusion criteria:; - Recruited from community health, hospital, and education-based early intervention services; - Clinical diagnosis of autism based on DSM-IV criteria; Exclusion criteria:; - See inclusion criteria; Age, months ± SD (range): 38.06 ± 5.49 (25–47) Mental age: NR Gender, n (%): Male: 14 (87) Female: 2 (13) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: DSM-IV Diagnostic category: NR Other characteristics: NR | Language/communication: CSBS score, median (range): Total: G1: 74.5 (65–126) Social: G1: 4 (3–11) Speech: G1: 9 (3–17) Symbolic: G1: 5.5 (3–13) CSBS caregiver questionnaire score, median (range): Total: G1: 84.5 (65–100) Social: G1: 4 (3–7) Speech: G1: 10 (3–17) Symbolic: G1: 7.5 (3–10) | Language/communication: CSBS score, median (range): Total: G1: 75 (65–135) G1/BL: P = 0.1 Social: G1: 5 (3–15) G1/BL: P = 0.122 Speech: G1: 8.5 (3–17) G1/BL: P = 0.194 Symbolic: G1: 6.5 (3–17) G1/BL: P = 0.203 CSBS caregiver questionnaire score, median (range): Total: G1: 90 (70–103) G1/BL: P = 0.007 Social: G1: 5.5 (3–9) G1/BL: P = 0.017 Speech: G1: 10.5 (7–17) G1/BL: P = 0.044 Symbolic: G1: 7 (5–11) G1/BL: P = 0.007 Harms: NR Modifiers: No significant relationships found between child/parent variables and change in behavior sample scores

Kroeger et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Kroeger et al., 2007 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: Xavier University Mentoring and Project Chair Award, Autism Society of Greater Cincinnati Student Researcher Grant Design: RCT | Intervention: In both interventions (direct teaching and play activities), the child participates for a total of 15 hours in 15 group sessions, which include:; - Beginning and ending circle times; - Visual schedules during each session to transition activities; - 2:1 student to facilitator ratio; - Secondary (social) reinforcement for prosocial behaviors; - Behavior management for inappropriate behaviors; - Introduction of identical toys and materials commensurate with the video modeling curriculum; In the direct teaching intervention, children participated in the video modeling curriculum and received primary (edible) reinforcement during the course of the video modeling In the play activities intervention, children engaged in supervised free play during the middle portion of the session instead of video modeling Assessments: Parent satisfaction survey; Social Interaction Observation Code videotape data Groups: G1: direct teaching G2: play activities Provider: Group supervisor and facilitators | Inclusion criteria:; - 4–6 years old; - Diagnosed with Autistic disorder; Exclusion criteria:; - Other autism spectrum disorders (i.e. Asperger’s disorder, Rett’s disorder, childhood disintegrative disorder, and pervasive developmental disorder, NOS); Age, months ± SD: G1: 65.00 ± 12.25 G2: 61.42 ± 9.15 Mental age: NR Gender, n: Male: G1: 9 G2: 11 Female: G1: 4 G2: 1 Race/ethnicity, n: Caucasian: G1: 9 G2: 12 African American: G1: 4 G2: 0 SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: By developmental pediatrician following routine multidisciplinary assessment: parent and a variety of autism and developmental standardized assessments conducted by corresponding professionals Diagnostic category, n (%): Autism: 25 (100) | Social skills: Number of initiating behaviors: G1: NR^*^ G2: NR^*^ G1/G2: P = NS Number of responding behaviors: G1: NR^*^ G2: NR^*^ G1/G2: P = NS Number of inter-acting behaviors: G1: NR^*^ G2: NR^*^ G1/G2: P = NS | Overall: Parent satisfaction rating, mean: G1: 5.69 G2: 5.67 G1/G2: P = NS Social skills: Number of initiating behaviors: G1: NR^*^ G2: NR^*^ ANOVA: time (P = 0.001), treatment (0.020) η^2^ = 0.215 Number of responding behaviors: G1: NR^*^ G2: NR^*^ ANOVA: time (P = 0.005), treatment (P = 0.003) η^2^ = 0.328 Number of inter-acting behaviors: G1: NR^*^ G2: NR^*^ ANOVA: time (P = 0.002), treatment (P = 0.006); η^2^ = 0.288 Harms: NR Modifiers: NR
| Mean # of sessions attended: G1: 14.08 G2: 14.42 Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 14 G2: 13 N at follow-up: G1: 13 G2: 12 | Other characteristics: GARS score, mean ± SD: G1: 92.15 ± 15.24 G2: 92.58 ± 9.66 G1/G2: P = NS Non-verbal G1: 2 G2: 2

Comments:

* Data only illustrated graphically

Magiati et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Magiati et al., 2007 Country: UK Practice setting: Academic Intervention setting: Community Enrollment period: July 1998 to July 2002 Funding: Local educational authorities Author industry relationship disclosures: None Design: Prospective cohort | Intervention: Early Intensive Behavioral Intervention: children received 1:1 home teaching using discrete trial techniques and Verbal Behavior; 27 families attended an initial workshop of 1–3 days Nursery: eclectic intervention, emphasizing structure, visual cues, individualized teaching, and contact with families (most commonly reported TEACCH, PECS, Makatan, and SPELL) Duration of treatment, months ± SD (range): G1: 25.5 ± 1.04 (23–27) G2: 26.0 ± 1.5 (23–27) Total hours of intervention, mean ± SD: G1: 3,415 ± 444 G2: 2,266 ± 533 Hours of intervention per week, mean ± SD (range): First week: G1: 32.4 ± 6.4 (18–40) G2: 25.6 ± 6.4 (15–30) G1/G2: P < 0.001 Last week: G1: 33.2 ± 3.5 (26–40) G2: 27.4 ± 4.2 (19–30) G1/G2: P < 0.001 Assessments: BSID, WPPSI, MPS, VABS, BPVS-II, Word Picture Vocabulary Test- Revised, Symbolic Play Test-II, Test of Pretend Play, administered at home or school by investigators at baseline and follow-up Groups: G1: EIBI G2: nursery | Inclusion criteria:; - Age 22–54 months; - Independent professional diagnosis of autism/ASD confirmed by ADI-R; - No major medical diagnoses; - English main language at home; - Living within 3 hours of London; - Enrolled in either EIBI home-based program or specialist autism- specific school-based nursery provision for a minimum of 15 hours per week; - Receiving no other intensive treatment; Exclusion criteria:; - See inclusion criteria; Age, months ± SD: G1: 38 ± 7.2 G2: 42.5 ± 7.8 Mental age, mean ± SD (range): See baseline measures Gender, n (%): Male: G1: 27 (96.4) G2: 12 (75) Female: G1: 1 (3.6) G2: 4 (25) Race/ethnicity, n (%): White: G1: 21 (47) G2: 11 (69) Mixed: G1: 4 (9) G2: 0 Asian/Asian British: G1: 2 (45) G2: 2 (13) Black/Black British: G1: 1 (2) G2: 3 (19) | Overall measures: VABS composite, standard score, mean ± SD (range): G1: 59.6 ± 6.2 (50–72) (n=26) G2: 55.4 ± 5.4 (47–64) (n=14) G1/G2: P = 0.04 ADI-R total algorithm score, mean ± SD (range): G1: 36.4 ± 6.7 (18–46) (n=26) G2: 40 ± 6.9 (18–46) (n=15) G1/G2: P = NS Educational/cognitive/academic attainment: Mental age, months ± SD (range): G1: 31.4 ± 11.1 (5–55 ) G2: 29.1 ± 13.1 (9–48) G1/G2: P = NS IQ, mean ± SD (range): G1: 83 ± 27.9 (16–138) G2: 65.2 ± 26.9 (27–112 ) G1/G2: P = 0.04 Symbolic play test score, developmental age, months ± SD (range): G1: 18.8 ± 8 (12–36) (n=27) G2: 19.2 ± 8.6 (12–34) G1/G2: P = NS BPVS score, mean ± SD (range): G1: 4.9 ± 9.1 (0–32) G2: 2.9 ± 7.7 (0–27) G1/G2: P = NS | Overall measures: VABS composite, age equivalent, months ± SD (range): G1: 32.6 ± 10.2 (19–58) G2: 26.1 ± 12.4 (11–48) G1/G2: P = NS VABS composite, standard score, mean ± SD (range): G1: 57.5 ± 10.1 (41–79) G2: 48.6 ± 10.7 (35–72) G1/G2: P = NS ADI-R total algorithm score, mean ± SD (range): G1: 30.7 ± 8.8 (13–40) (n=26) G2: 34.9 ± 9.9 (11–48) G1/G2: P = NS Educational/cognitive/academic attainment: Mental age, months ± SD (range): G1: 49.2 ± 9.8 (29–70) G2: 44.7 ± 14.1 (17–67) (n=15) G1/G2: P = NS IQ, mean ± SD (range): G1: 78.4 ± 17.6 (43–129) G2: 65.3 ± 18 (30–94) (n=15) G1/G2: P = NS
| Provider: EIBI provider, n (%): Supervisor and consultant: 14 (50) Supervisor: 7 (25) Consultant: 3 (11) Senior therapist: 2 (7) One-two parents trained as a therapist: 23 (82) Nursery provider, n (%): Teachers: 16 (100) Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies, n: Special Dietary: G1: 21 G2: 6 G1/G2: P = 0.01 Other biological interventions: G1: 17 G2: 3 G1/G2: P = 0.01 Extra-curricular educational interventions: G1: 2 G2: 7 G1/G2: P < 0.01 Other alternative treatments: G1: 8 G2: 2 G1/G2: P = 0.18 N at enrollment: G1: 28 G2: 16 N at follow-up: G1: 28 G2: 16 | SES: Parental education, n: Higher (degree or above): G1: 18 G2: 7 Lower (A-levels or below): G1: 5 G2: 8 No information: G1: 5 G2: 1 Family SEC, n: Higher (categories 1–3): G1: 23 G2: 9 Lower (categories 4–9): G1: 4 G2: 6 No information: G1: 1 G2: 1 Diagnostic approach: In Study Diagnostic tool/method: ADI-R Diagnostic category, n (%): Autism: G1: 19 (43) G2: 13 (81) ASD: G1: 9 (20) G2: 3 (19) Other characteristics: NR | Communication/language: EOWPVT-R score, mean ± SD (range): G1: 2.2 ± 7.8 (0–39) G2: 1.7 ± 3.7 (0–12) G1/G2: P = NS VABS communication, age equivalent, months ± SD (range): G1: 14.4 ± 5.2 (8–28) (n=26) G2: 13.1 ± 4.5 (8–26) (n=14) G1/G2: P = NS VABS communication, standard score, mean ± SD (range): G1: 60 ± 7.4 (50–78) (n=26) G2: 55.8 ± 6.8 (47–74) (n=14) G1/G2: P = NS Adaptive behavior: VABS daily living, age equivalent, months ± SD (range): G1: 19 ± 6.1 (11–39) (n=26) G2: 20 ± 3.9 (15–27) (n=14) G1/G2: P = NS VABS daily living, standard score, mean ± SD (range): G1: 63 ± 7.4 (55–89) (n=26) G2: 61.4 ± 4.9 (52–69) (n=14) G1/G2: P = NS Social skills: VABS socialization, age equivalent, months ± SD (range): G1: 13 ± 4.4 (6–24) (n=26) G2: 11.1 ± 3.4 (6–20) (n=14) G1/G2: P = NS | Symbolic play test score, developmental age, months ± SD (range): G1: 29.2 ± 12.7 (12–65) G2: 28.8 ± 13 (12–61) (n=15) G1/G2: P = NS BPVS score, mean ± SD (range): G1: 20.8 ± 20.8 (0–68) (n=27) G2: 13.2 ± 17.8 (0–52) (n=15) G1/G2: P = NS Communication/language: EOWPVT-R score, mean ± SD (range): G1: 13 ± 17.3 (0–59) (n=27) G2: 10.2 ± 13.7 (0–38) (n=15) G1/G2: P = NS VABS communication, age equivalent, months ± SD (range): G1: 29.6 ± 17.2 (12–70) G2: 23.6 ± 16.8 (11–67) G1/G2: P = NS VABS communication, standard score, mean ± SD (range): G1: 61.2 ± 17.6 (41–106) G2: 51.6 ± 14.8 (37–87) G1/G2: P = NS
| | | VABS socialization, standard score, mean ± SD (range): G1: 60.3 ± 6 (51–76) (n=26) G2: 56.6 ± 4.8 (52–67) (n=14) G1/G2: P = 0.05 VABS composite, age equivalent, months ± SD (range): G1: 18.6 ± 5.4 (12–32) (n=26) G2: 17.3 ± 3.9 (12–26) (n=14) G1/G2: P = NS | Adaptive behavior: VABS daily living, age equivalent, months ± SD (range): G1: 32.4 ± 8.2 (20–55) G2: 29.4 ± 9.7 (17–49) G1/G2: P = NS VABS daily living, standard score, mean (SD); range: G1: 58.6 ± 8.4 (38–78) G2: 49.6 ± 12.4 (28–73) G1/G2: P = 0.06 Social skills: VABS socialization, age equivalent, months ± SD (range): G1: 25.1 ± 11.8 (12–61) G2: 20.2 ± 14 (7–53) G1/G2: P = NS VABS socialization, standard score, mean ± SD (range): G1: 61.8 ± 10.4 (41–90) G2: 56.7 ± 10.3 (47–82) G1/G2: P = NS Harms: NR
| | | | Modifiers: Progress after 2 years was best predicted by baseline IQ (P < 0.001) and baseline PBVS score (P < 0.01); VABS and ADI-R total scores also contributed to the model (P < 0.05)

Pandina et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Shea et al., 2004 Pandina et al., 2007† Country: Canada Practice setting: Academic, tertiary care hospital, pharmaceutical company, contract research organization Intervention setting: Clinic Enrollment period: NR Funding: Janssen-Ortho, Inc., Canada; Johnson & Johnson Pharmaceutical Research and Development Author industry relationship disclosures: 1 of 7 Janssen-Ortho (1) 5 of 5† Janssen (4) Janssen-Ortho (1) Design: RCT | Intervention: Risperidone oral solution 1.0 mg/mL once daily in the morning at 0.01 mg/kg/day on treatment days 1–2, increased to 0.02 mg/kg/day on day 3. Depending on response at day 8, could be increased in increments up to 0.02 mg/kg/day. Thereafter adjusted at investigator’s discretion weekly in increments ≤ 0.02 mg/kg/day up to max allowable dosage of 0.06 mg/kg/day. Duration: days (range): G1: 52.7 (2–62) G2: 49.6 (7–63) Planned: 8 weeks Assessments: CGI-S completed at intake by investigator ESRS, VAS-MS (most troublesome symptom) CGI-C by investigator weekly ABC, N-CBRF (parent version) completed weekly by parent with investigator guidance Groups: G1: risperidone oral solution G2: placebo oral solution Ga: diagnosis of autism Co-interventions held stable during treatment: Yes Frequency of contact during study: Weekly for 8 weeks Concomitant therapies: At least one concomitant medication, n (%): G1: 36 (90) G2: 26 (66.7) Medication, %: Analgesics: G1: 37.5 G2: 17.9 | Inclusion criteria:; - Physically healthy outpatients; - Ages 5–12 years; - DSM-IV Axis 1 diagnosis of PDD; - CARS total score ≥ 30 with or without mental retardation; Exclusion criteria:; - Schizophrenia; - Other psychotic disorders; - Clinically relevant non- neurologic disease; - Clinical significant laboratory abnormalities; - Seizure disorder for which they were receiving one or more anticonvulsants or had a seizure within 3 months; - History of hypersensitivity to neuroleptics, tardive dyskinesia, narcoleptic malignant syndrome, drug or alcohol abuse, or HIV infection; - Used risperidone in the last 3 months, previously unresponsive or intolerant to risperidone; - Using a prohibited medication (including antipsychotics other than study medication, antidepressants, lithium, α_2_-antagonists, clonidine, guanfacine, cholinesterase inhibitors, psychostimulants, and naltrexone); Age, years ± SD (range): G1: 7.6 ± 2.3 (5–12) G1a: 7.4 ± 2.4 (NR)† G2: 7.3 ± 2.3 (5–12) G2a: 7.1 ± 2.1 (NR)† | Problem behavior: ABC score, mean ± SD: Irritability: G1: 18.9 ± 8.8 G1a: 20.6 ± 8.1 (n=24)† G2: 21.2 ± 9.7 G2a: 21.6 ± 10.2† Lethargy: G1: 13.7 ± 7.0 G1a: 14 ± 6.8 (n=26)† G2: 14.3 ± 8.2 G2a: 13 ± 8.6† Stereotypic behavior: G1: 7.9 ± 5.0 G1a: 8.4 ± 5.8 (n=25)† G2: 8.1 ± 5.6 G2a: 9.4 ± 5.5† Hyperactivity/non- compliance: G1: 27.3 ± 9.7 G1a: 29.2 ± 9.5 (n=25)† G2: 30.9 ± 8.8 G2a: 33.6 ± 6.8 (n=27)† Inappropriate speech: G1: 4.6 ± 3.4 G1a: 4.5 ± 3.7 (n=26)† G2: 4.8 ± 3.7 G2a: 4.5 ± 3.7† N-CBRF score, parent rated, mean ± SD: Adaptive/social:† G1a: 3.8 ± 2.3 (n=26) G2a: 3.9 ± 2 Compliant/Calm:† G1a: 6.8 ± 2.7 (n=25) G2a: 6.2 ± 2.4 (n=26) | Problem behavior: ABC score, mean change ± SD: Irritability: G1: −12.1 ± 5.8 G2: −6.5 ± 8.4 G1/G2: P ≤ 0.001 Lethargy: G1: −8.6 ± 5.9 G2: −5.7 ± 6.9 G1/G2: P ≤0.01 Stereotypic Behavior: G1: −4.3 ± 3.8 G2: −2.4 ± 4.0 G1/G2: P ≤ 0.05 Hyperactivity/noncompliance: G1: −14.9 ± 6.7 G2: −7.4 ± 9.7 G1/G2: P ≤ 0.001 Inappropriate speech: G1: −2.6 ± 2.6 G2: −1.6 ± 3.0 G1/G2: P ≤ 0.05 ABC score, mean ± SD: Irritability:† G1a: 7.2 ± 5.9 (n=24) G2a: 14.1 ± 11.3 G1a/G2a: P = 0.002 Lethargy: G1a: 4.7 ± 4.4 (n=26) G2a: 8.2 ± 8.9 G1a/G2a: P = 0.020 Stereotypic Behavior: G1a: 3.9 ± 4.2 (n=25) G2a: 6.9 ± 6.9 G1a/G2a: P = 0.053
| Cough and cold preparations: G1: 25 G2: 10.3 Antibiotics: G1: 12.5 G2: 12.8 Anti-asthmatics: G1: 15 G2: 10 Sedative/hypnotics: G1: 27.5 G2: 23.1 Anticholinergics: G1: 7.5 G2: 2.6 N at enrollment: G1: 40 G1a: 27 G2: 39 G2a: 28 N at follow-up: G1: 39 G1a: 25 G2: 38 G2a: 24 | Mental age: IQ score, n (%): ≥ 85, normal: G1: 3/31 (9.7) G1a: 0† G2: 11/35 (31.4) G2a: 6/24 (25)† 71–84, borderline: G1: 6/31 (19.4) G2: 4/35 (11.4) 50–70, mild: G1: 12/31 (38.7) G2: 8/35 (22.9) 35–49, moderate: G1: 10/31 (32.3) G2: 12/35 (34.3) IQ, mean ± SD:† G1a: 50.8 ± 19.8 G2a: 60.1 ± 26.9 Gender, n (%): Male: G1: 29 (72.5) G1a: 19 (70)† G2: 32 (82.1) G2a: 24 (86)† Female: G1: 11 (27.5) G1a: 8 (30)† G2: 7 (17.9) G2a: 4 (14)† Race/ethnicity, n (%): G1: White: G1: 27 (67.5) G1a: 16 (59)† G2: 28 (71.8) G2a: 18 (64)† Black: G1: 6 (15.0) G1a: 4 (15)† G2: 6 (15.4) G2a: 6 (21)† Other: G1: 7 (17.5) G1a: 7 (26)† G2: 5 (12.8) G2a: 4 (14)† SES: Maternal education: NR Household income: NR Diagnostic approach: In Study | Conduct problem: G1: 16.8 ± 9.4 G1a: 17.2 ± 8 (n=26)† G2: 23.3 ± 12.0 G2a: 21.5 ± 10.7† Hyperactive: G1: 17.2 ± 5.8 G1a: 17.7 ± 5.6 (n=25)† G2: 18.9 ± 5.3 G2a: 19.6 ± 5.2† Insecure/anxious: G1: 8.7 ± 8.1 G1a: 6.3 ± 6.7 (n=26)† G2: 10.6 ± 7.6 G2a: 8.7 ± 6.7† Overly sensitive: G1: 6.9 ± 3.4 G1a: 6.7 ± 3.4 (n=26)† G2: 7.4 ± 3.5 G2a: 6.6 ± 3.4† Self-injury/stereotypic: G1: 4.2 ± 4.2 G1a: 4.5 ± 4.4 (n=26)† G2: 3.5 ± 4.2 G2a: 4.1 ± 4.4† Self-isolated/ritualistic: G1: 7.5 ± 4.1 G1a: 7.3 ± 4 (n=26)† G2: 8.2 ± 4.5 G2a: 7.8 ± 4.2† VAS-MS, mean ± SD: G1: 81.0 ± 13.3 G2: 84.8 ± 14.1 VAS-MS score by symptom, mean ± SD:† Aggression: G1a: 86 ± 14.5 (n=7) G2a: 88.3 ± 9 (n=7) | Hyperactivity/noncompliance: G1a: 13.3 ± 8.7 (n=25) G2a: 26.4 ± 12.8 (n=27) G1a/G2a: P = 0.001 Inappropriate speech: G1a: 1.9 ± 2.2 (n=26) G2a: 3.1 ± 3.5 G1a/G2a: P = 0.058 N-CBRF score, parent rated, mean change ± SD: Conduct problem: G1: −10.4 ± 7.4 G2: −6.6 ± 9.5 G1/G2: P ≤ 0.001 Hyperactive: G1: −8.1 ± 4.6 G2: −5.6 ± 6.6 G1/G2: P ≤ 0.05 Insecure/anxious: G1: −4.6 ± 6.5 G2: −3.5 ± 5.5 G1/G2: P ≤ 0.05 Overly sensitive: G1: −3.8 ± 2.8 G2: −2.7 ± 3.2 G1/G2: P ≤ 0.05 Self-injurious/stereotypic: G1: −2.6 ± 3.3 G2: −1.3 ± 2.8 G1/G2: P = NS Self-isolated/ritualistic: G1: −4.8 ± 3.9 G2: −3.6 ± 4.6 G1/G2: P = NS
| | Diagnostic tool/method: DSM-IV Diagnostic category, n (%): Autism: G1: 27 (67.5) G2: 28 (71.8) Asperger: G1: 5 (12.5) G2: 7 (17.9) Childhood disintegrative disorder: G1: 1 (2.5) G2: 0 PDD-NOS: G1: 7 (17.5) G2: 4 (10.3) Other characteristics: Weight, kg ± SD: G1: 31.2 ± 14.5 G2: 27.6 ± 8.6 VABS composite score, mean ± SE: G1: 46.6 ± 13.1 G1a: 44.6 ± 13.8† G2: 52.2 ± 19.8 G2a: 46.7 ± 19.7† CARS score, mean ± SE: G1: 38.9 ± 5.3 G1a: 40.1 ± 5.4† G2: 39.1 ± 6.7 G2a: 50.9 ± 6.6† CARS score, n (%): 31–36, mild/moderate: G1: 17 (42.5) G2: 18 (46.2) 37–60, severe: G1: 23 (57.5) G2: 21 (53.8) | Defiance/disobedience: G1a: 75 ± 47 (n=7) G2a: 84.8 ± 19.6 (n=7) Hyperactivity: G1a: 68.7 ± 28.6 (n=7) G2a: 96.3 ± 4.2 (n=7) Obsessive/repetitive: G1a: 86.3 ± 19.4 (n=7) G2a: 98 ± 0 (n=7) Tantrums/negative mood: G1a: 80.8 ± 10.1 (n=7) G2a: 81.2 ± 13.9 (n=7) Medical: Pulse, mean bpm ± SD: G1: 90.2 ± 12.0 G2: 95.0 ± 13.7 Diastolic BP, mean mm Hg ± SD: G1: 68.1 ± 9.8 G2: 67.8 ± 10.3 Systolic BP, mean mm Hg ± SD: G1: 99.8 ± 9.6 G2: 100.4 ± 10.5 Weight, mean kg ± SD: G1: 31.2 ± 14.5 G2: 27.5 ± 8.7 | N-CBRF score, parent rated, mean ± SD:† Adaptive/social: G1a: 5.3 ± 2.4 (n=26) G2a: 4.3 ± 2.4 G1a/G2a: P = 0.072 Compliant/calm: G1a: 8.7 ± 3.3 (n=25) G2a: 6.9 ± 2.9 (n=26) G1a/G2a: P = 0.072 Conduct problem: G1a: 6.5 ± 5.7 (n=26) G2a: 15.5 ± 11.9 G1a/G2a: P = 0.005 Hyperactive: G1a: 9.4 ± 5.4 (n=25) G2a: 14.9 ± 8.4 G1a/G2a: P = 0.021 Insecure/anxious: G1a: 3.2 ± 4.3 (n=26) G2a: 5.4 ± 4.8 G1a/G2a: P = NS Overly sensitive: G1a: 2.8 ± 2.3 (n=26) G2a: 4.3 ± 3.3 G1a/G2a: P = 0.029 Self-injury/stereotypic: G1a: 2.2 ± 3.1 (n=26) G2a: 2.8 ± 3.9 G1a/G2a: P = NS Self-isolated/ritualistic: G1a: 2.4 ± 2.5 (n=26) G2a: 4.5 ± 5.5 G1a/G2a: P = 0.078
| | | | VAS-MS, mean change ± SD: G1: −38.4 ± 28.9 G2: −26.2 ± 29.2 G1/G2: P ≤ 0.05 VAS-MS score by symptom, mean ± SD:† Aggression: G1a: 22.3 ± 20 (n=7) G2a: 63.4 ± 37.3 (n=8) G1a/G2a: P = 0.056 Defiance/disobedience: G1a: 60 ± 12.1 (n=4) G2a: 65.2 ± 25 (n=5) G1a/G2a: P = NS Hyperactivity: G1a: 39.7 ± 19.7 (n=3) G2a: 80.5 ± 14.2 (n=4) G1a/G2a: P = 0.04 Obsessive/repetitive: G1a: 70 ± 16.8 (n=3) G2a: 48 ± 63.4 (n=2) G1a/G2a: P = NS Tantrums/negative mood: G1a: 28 ± 20.9 (n=6) G2a: 43.4 ± 28.8 (n=5) G1a/G2a: P = NS Medical: Pulse, mean change bpm ± SD: G1: 8.9 ± 13.9 G2: −0.6 ± 13.1 G1/G2: P ≤ 0.01
| | | | Diastolic BP, mean change mm Hg ± SD: G1: 0.7 ± 9.1 G2: −0.7 ± 8.8 G1/G2: P = NS Systolic BP, mean change mm Hg ± SD: G1: 4.0 ± 10.4 G2: −0.7 ± 10.7 G1/G2: P ≤ 0.01 Weight, mean change kg ± SD: G1: 2.7 ± 2.0 G2: 1.0 ± 1.6 G1/G2: P ≤ 0.001 Harms, n (%): Any event: G1: 40 (100) G2: 31 (79.5) Somnolence: G1: 29 (72.5) G2: 3 (7.7) Upper respiratory tract infection: G1: 15 (37.5) G2: 6 (15.4) Rhinitis: G1: 11 (27.5) G2: 4 (10.3) Increased appetite: G1: 9 (22.5) G2: 4 (10.3) Abdominal pain: G1: 8 (20.0) G2: 3 (7.7) Fever: G1: 8 (20) G2: 7 (17.9) Insomnia: G1: 6 (15.0) G2: 6 (15.4) Vomiting: G1: 6 (15.0) G2: 6 (15.4) Coughing: G1: 6 (15.0) G2: 4 (10.3) Headache: G1: 5 (12.5) G2: 2 (5.1)
| | | | Constipation: G1: 5 (12.5) G2: 1 (2.6) Apathy: G1: 5 (12.5) G2: 0 Tachycardia: G1: 5 (12.5) G2: 0 Influenza-like symptoms: G1: 4 (10.0) G2: 2 (5.1) Anorexia: G1: 4 (10.0) G2: 1 (2.6) Fatigue: G1: 4 (10.0) G2: 1 (2.6) Saliva increased: G1: 4 (10) G2: 1 (2.6) Weight increase: G1: 4 (10) G2: 1 (2.6) Tremor: G1: 4 (10) G2: 0 Modifiers: NR

Reed et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Reed et al., 2007 Country: UK Practice setting: Academic Intervention setting: Home Enrollment period: NR Funding: South East Region Special Education Needs Partnership Author industry relationship disclosures: NR Design: Non randomized controlled trial | Intervention: High-intensity ABA vs. low-intensity ABA High-intensity intervention offered home-based mostly 1:1 training between 20–40 hours per week (mean 30.4 hours); approaches included:; - Lovaas (discrete-trial reinforcement-based); - Verbal behavior (discrete-trial focused on developmental of verbal responses); - CABAS-based (combination of ABA technologies, stresses importance of learn- units); Each session lasted 2–3 hours. Low-intensity intervention offered training between 10–20 hours per week (mean 12.6 hours) using similar procedures as described in high-intensity intervention with up to four 3-hour home based direct 1:1 teaching sessions each week. Assessments: Blinded educational psychologist administered BAS and PEP-R. Parent completed VABS and GARS measures pre- and post-treatment (9–10 months) Groups: G1: high-intensity G2: low-intensity Ga: Lovaas Gb: verbal behavior Gc: CABAS | Inclusion criteria:; - Age 2.5–4 years at start of study; - At start of intervention; - Received no other major interventions during the assessment period; - Diagnosed with ASD; Exclusion criteria:; - See inclusion criteria; Age, months ± SD: G1: 42.9 ± 14.8 G1a: 47.5 ± 13.5 G1b: 38.0 ± 9.9 G1c: 44.2 ± 20.5 G2: 40.8 ± 5.6 Mental age: See baseline measures Gender, n (%): Male: G1: 14 (100) G2: 13 (100) Female: G1: 0 G2: 0 Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: NR Diagnostic tool/method: NR Diagnostic category: NR Other characteristics: NR | Overall ratings: GARS autism quotient, mean ± SD: G1: 89.1 ± 14.7 G1a: 93.0 ± 19.9 G1b: 87.6 ± 11.1 G1c: 87.4 ± 16.1 G2: 95.1 ± 11.6 Adaptive Behavior: VABS composite score, mean ± SD: G1: 59.3 ± 10.1 G1a: 59.8 ± 16.7 G1b: 58.2 ± 6.5 G1c: 60.0 ± 8.6 G2: 56.5 ± 4.4 Educational/cognitive/academic attainment: PEP-R overall score, mean ± SD: G1: 57.2 ± 17.8 G1a: 58.0 ± 30.7 G1b: 50.2 ± 7.7 G1c: 63.6 ± 12.4 G2: 49.3 ± 13.2 BAS cognitive ability score, mean ± SD: G1: 60.1 ± 22.4 G1a: 72.0 ± 30.6 G1b: 48.0 ± 4.6 G1c: 62.8 ± 23.9 G2: 52.4 ± 9.9 | Overall ratings: GARS autism quotient, mean change ± SD: G1: −2.2 ± 7.8 G2: 1.6; ± 6.2 G1/BL: P = NS G2/BL: P = NS G1/G2: P = NS Adaptive behavior: VABS composite score, mean change (ES^**^): G1: NR^*^ G1a: NR^*^ (0.03) G1b: NR^*^ (0.18) G1c: NR^*^ (0.53) G2: NR^*^ G1/BL: P = NS G1a/BL: P = NS G1b/BL: P = NS G1c/BL: P = NS G2/BL: P = NS G1/G2: P = NS G1a/G1b/G1c: P = NS Educational/cognitive/academic attainment: PEP-R overall score, mean change (ES^**^): G1: NR^*^ G1a: NR^*^ (0.91) G1b: NR^*^ (0.82) G1c: NR^*^ (1.11) G2: NR^*^ G1/BL: P < 0.01 G1a/BL: P < 0.05 G1b/BL: P = NS G1c/BL: P < 0.05 G2/BL: P = NS G1/G2: P = NS G1a/G1b/G1c: P < 0.05
| Provider: High-intensity programs were supervised by tutors trained in the approach who provided supervision on average of once every two weeks; low intensity was provided by trained assistants Measure of treatment fidelity reported: No Co-interventions held stable during treatment: Yes Concomitant therapies: NR N at enrollment: G1: 14 G1a: 4 G1b: 5 G1c: 5 G2: 13 N at follow-up: G1: 14 G1a: 4 G1b: 5 G1c: 5 G2: 13 | | | BAS cognitive ability score, mean change (ES^**^): G1: NR^*^ G1a: NR^*^ (0.58) G1b: NR^*^ (3.74) G1c: NR^*^ (3.74) G2: NR^*^ G1/BL: P < 0.01 G1a/BL: P = NS G1b/BL: P = NS G1c/BL: P < 0.01 G2/BL: P < 0.05 G1/G2: P < 0.01 G1a/G1b/G1c: P = NS Harms: NR Modifiers: Increases in hours/week of intervention were associated with decreases in mean-outcome gains for G1^*^

Comments:

* data only illustrated graphically

** Effect sizes were calculated by dividing the change score by the original standard deviation of the sample

Reed et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Reed et al., 2007 Country: UK Practice setting: Community Intervention setting: Home or school Enrollment period: 2002 to 2004 Funding: South East Regional Special Educational Needs Partnership Author industry relationship disclosures: NR Design: Retrospective cohort Note: see related study, Reed et al. 2010 | Intervention: Applied Behavioral Analysis (ABA): 1:1 interaction for 2 to 3 hrs, approx 8 to 14 tasks or drills per session; programs used an antecedent (question/task), behavior (response) sometimes prompted if necessary, and consequence procedure; programs included Lovaas, verbal behavior, CABAS; all ABA programs overseen by either BCBA or CABAS- certified qualification Frequency: mean 30.4 hours per week (range 20–40) of intervention Special Nursery: group interaction for 2 to 3 hrs; a session would start and end with six to eight children in a group with the teacher at the front; individual tasks organized into highly structured method as outlined by the TEACCH methodology Frequency: mean 12.7 hours per week (range 3–23) of intervention Portage: supervisor visits the parents once every 1 to 2 weeks, and parents and caregivers are shown how to apply this system during these visits; 1:1 situation targeting several skills/week; 40 to 60 min/day, scheduled when the parent believes the child will be at his or her most receptive; children are taught new skills through the use of questions and tasks, prompts, and rewards Frequency: mean 8.5 hours per week (range 2–15) of intervention | Inclusion criteria:; - Age 2.5 to 4 years old; - Beginning their first teaching intervention; - Independent diagnosis of ASD made by specialist pediatrician following initial referral from a general medical practitioner; Exclusion criteria:; - Receiving other major intervention during the assessment period; Age, months (range): G1: 40 (32–47) G2: 43 (41–48) G3: 38 (30–45) Mental age: NR Gender, n (%): Male: G1: 11 (92) G2: 18 (90) G3: NR Female: G1: 1 (8) G2: 2 (10) G3: NR Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: GARS, CRS-R Diagnostic category, n (%): Autism: 48 (100) Other characteristics: NR | Overall ratings: GARS total score, mean ± SD: G1: 90.5 ± 13.9 G2: 96.8 ± 10.4 G3: 91.3 ± 14.3 PEP-R total score, mean ± SD: G1: 55.6 ± 13.8 G2: 51.9 ± 20.1 G3: 53.3 ± 16.1 BAS II total score, mean ± SD: G1: 56.8 ± 16.6 G2: 57.8 ± 12.8 G3: 53.4 ± 10.9 Repetitive behaviors: GARS stereotyped behaviors score, mean ± SD: G1: 8.1 ± 2.8 G2: 9.3 ± 2.3 G3: 8.9 ± 3.1 Communication/language: GARS communication score, mean ± SD: G1: 1.6 ± 3.3 G2: 5.9 ± 5.6 G3: 0.4 ± 1.8 Social skills: GARS social interaction score, mean ± SD: G1: 7.4 ± 2.7 G2: 9.1 ± 2.8 G3: 8.3 ± 2.9 GARS developmental disturbance score, mean ± SD: G1: 9.2 ± 2.3 G2: 9.6 ± 1.9 G3: 9.2 ± 1.8 PEP-R imitation score, mean ± SD: G1: 45.5 ± 30.9 G2: 52.9 ± 30.3 G3: 39.4 ± 22.1 | Overall ratings: GARS total score, mean change ± SD: G1: −2.0 ± 8.4 G2: 0.5 ± 9.3 G3: 1.5 ± 5.9 G1/G2/G3: P = NS PEP-R total score, mean change ± SD: G1: 13.6 ± 12.7 G2: 10.2 ± 13.6 G3: 1.6 ± 11.2 G1/G2: P = NS^*^ G1/G3: P < 0.05^*^ G2/G3: P = NS^*^ BAS II total score, mean change ± SD: G1: 17.8 ± 15.0 G2: 7.9 ± 8.6 G3: 6.6 ± 9.1 G1/G2: P < 0.05^*^ G1/G3: P < 0.05^*^ G2/G3: P = NS^*^ Social skills: GARS social interaction score, mean change ± SD: G1: −0.4 ± 1.6 G2: −0.6 ± 2.5 G3: 0.1 ± 1.1 G1/BL: P = NS^*^ G2/BL: P = NS^*^ G3/BL: P = NS^*^ G1/G2: P = NS^*^ G1/G3: P = NS^*^ G2/G3: P = NS^*^ VABS socialization score, mean change ± SD: G1: 4.0 ± 7.3 G2: 5.0 ± 8.8 G3: −0.3 ± 3.9 G1/BL: P = NS^*^ G2/BL: P < 0.05 G3/BL: P = NS^*^ G1/G2: P = NS^*^ G1/G3: P = NS^*^ G2/G3: P = NS^*^
| Assessments: Initial and follow-up assessment handled by senior educational psychologist Groups: G1: ABA G2: special nursery G3: portage Provider: G1: either board certified behavior analyst or master teaching-level CABAS qualifications G2: trained teacher G3: parents with super- vision by trained provider Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 12 G2: 20 G3: 16 N at follow-up: G1: 12 G2: 20 G3: 16 | | PEP-R perception score, mean ± SD: G1: 78.2 ± 24.6 G2: 80.4 ± 45.6 G3: 74.8 ± 31.3 VABS socialization score, mean ± SD: G1: 62.1 ± 9.3 G2: 62.1 ± 9.3 G3: 61.0 ± 5.8 Motor Skills: PEP-R fine motor score, mean ± SD: G1: 71.5 ± 18.7 G2: 59.9 ± 21.0 G3: 65.0 ± 19.9 PEP-R gross motor score, mean ± SD: G1: 60.3 ± 17.5 G2: 67.2 ± 28.2 G3: 68.3 ± 20.2 PEP-R hand-eye coordination score, mean ± SD: G1: 64.8 ± 21.7 G2: 66.0 ± 31.3 G3: 64.7 ± 28.0 VABS motor skills score, mean ± SD: G1: 73.8 ± 16.6 G2: 73.8 ± 16.6 G3: 70.9 ± 11.1 Educational/cognitive academic attainment: PEP-R cognitive score, mean ± SD: G1: 40.7 ± 23.2 G2: 42.5 ± 20.2 G3: 38.3 ± 17.6 Communication/language: PEP-R verbal score, mean ± SD: G1: 41.9 ± 22.6 G2: 43.8 ± 23.8 G3: 42.6 ± 15.9 | Communication/language: GARS communication score, mean ± SD: G1: 3.8 ± 5.5 G2: −1.3 ± 5.8 G3: 1.2 ± 3.1 G1/BL: P = NS^*^ G2/BL: P = NS^*^ G3/BL: P = NS^*^ G1/G2: P = NS^*^ G1/G3: P = NS^*^ G2/G3: P = NS^*^ PEP-R verbal score, mean change ± SD: G1: 19.8 ± 24.5 G2: 11.5 ± 15.3 G3: 31 ± 17.7 G1/BL: P < 0.05^*^ G2/BL: P < 0.01^*^ G3/BL: P = NS^*^ G1/G2: P = NS^*^ G1/G3: P = NS^*^ G2/G3: P = NS^*^ BAS II verbal comprehension score, mean change ± SD: G1: 9.5 ± 14.3 G2: 1.8 ± 4.1 G3: 0.7 ± 3.4 G1/BL: P < 0.05^*^ G2/BL: P = NS^*^ G3/BL: P = NS^*^ G1/G2: P < 0.05^*^ G1/G3: P < 0.05^*^ G2/G3: P = NS^*^ BAS II picture matching score, mean change ± SD: G1: 8.6 ± 8.8 G2: 7.9 ± 10.9 G3: 6.9 ± 7.6 G1/BL: P < 0.05^*^ G2/BL: P < 0.01^*^ G3/BL: P < 0.01^*^ G1/G2: P = NS^*^ G1/G3: P = NS^*^ G2/G3: P = NS^*^
| | | BAS II verbal comprehension score, mean ± SD: G1: 23.3 ± 6.8 G2: 23.3 ± 6.8 G3: 21.7 ± 4.3 BAS II picture matching score, mean ± SD: G1: 33.8 ± 13.3 G2: 33.8 ± 13.3 G3: 28.8 ± 8.0 BAS II naming score, mean ± SD: G1: 22.4 ± 8.3 G2: 22.4 ± 8.4 G3: 22.3 ± 6.3 BAS II early number skills score, mean ± SD: G1: 26.3 ± 5.3 G2: 26.3 ± 5.3 G3: 26.1 ± 7.8 VABS communication score, mean ± SD: G1: 57.1 ± 7.6 G2: 57.1 ± 7.6 G3: 57.1 ± 4.9 Adaptive behavior: VABS total score, mean ± SD: G1: 58.2 ± 8.0 G2: 53.0 ± 4.6 G3: 58.6 ± 6.0 VABS daily living skills score, mean ± SD: G1: 61.6 ± 6.7 G2: 61.6 ± 6.9 G3: 64.6 ± 6.2 Problem behavior: CRS-R score, mean ± SD: Oppositional: G1: 62.1 ± 9.9 G2: 70.4 ± 13.0 G3: 68.3 ± 6.1 Cognitive: G1: 72.4 ± 19.4 G2: 78.9 ± 10.9 G3: 74.9 ± 13.6 | BAS II naming score, mean change ± SD: G1: 13.2 ± 11.9 G2: 2.7 ± 4.0 G3: 1.7 ± 4.6 G1/BL: P < 0.01^*^ G2/BL: P < 0.01^*^ G3/BL: P = NS^*^ G1/G2: P < 0.05^*^ G1/G3: P < 0.05^*^ G2/G3: P = NS^*^ BAS II early number skills score, mean change ± SD: G1: 8.6 ± 9.6 G2: 4.3 ± 7.6 G3: 1.8 ± 8.6 G1/BL: P < 0.01^*^ G2/BL: P < 0.01^*^ G3/BL: P = NS^*^ G1/G2: P = NS^*^ G1/G3: P = NS^*^ G2/G3: P = NS^*^ VABS communication score, mean ± SD: G1: 7.0 ± 11.6 G2: 3.1 ± 6.4 G3: −2.3 ± 4.1 G1/BL: P = NS^*^ G2/BL: P < 0.05^*^ G3/BL: P < 0.05^*^ G1/G2: P = NS^*^ G1/G3: P < 0.05^*^ G2/G3: P = NS^*^ PEP-R imitation score, mean change ± SD: G1: 31.0 ± 22.8 G2: 8.2 ± 21.2 G3: 10.1 ± 23.6 G1/BL: P < 0.01^*^ G2/BL: P = NS^*^ G3/BL: P = NS^*^ G1/G2: P < 0.05^*^ G1/G3: P = NS^*^ G2/G3: P = NS^*^
| | | Hyperactivity: G1: 63.2 ± 8.2 G2: 68.6 ± 9.9 G3: 68.4 ± 6.3 ADHD: G1: 64.6 ± 7.2 G2: 69.0 ± 9.3 G3: 66.9 ± 7.1 | PEP-R perception score, mean change ± SD: G1: 21.6 ± 20.1 G2: 0.8 ± 34.6 G3: 1.9 ± 20.8 G1/BL: P < 0.01^*^ G2/BL: P = NS^*^ G3/BL: P = NS^*^ G1/G2: P = NS^*^ G1/G3: P = NS^*^ G2/G3: P = NS^*^ Repetitive behavior: GARS stereotyped behaviors score, mean change ± SD: G1: −1.0 ± 1.5 G2: 0.3 ± 2.1 G3: 0.1 ± 2.5 G1/BL: P = NS^*^ G2/BL: P = NS^*^ G3/BL: P = NS^*^ G1/G2: P = NS^*^ G1/G3: P = NS^*^ G2/G3: P = NS^*^ Problem behavior: CRS-R score, mean change ± SD: Oppositional: G1: −0.8 ± 10.1 G2: −10.7 ± 11.4 G3: −9.9 ± 6.3 G1/BL: P = NS^*^ G2/BL: P = NS^*^ G3/BL: P = NS^*^ G1/G2: P < 0.05^*^ G1/G3: P < 0.05^*^ G2/G3: P = NS^*^ Cognitive: G1: −10.4 ± 26.6 G2: −16.1 ± 14.1 G3: 0.4 ± 13.2 G1/BL: P = NS^*^ G2/BL: P = NS^*^ G3/BL: P = NS^*^ G1/G2: P = NS^*^ G1/G3: P = NS^*^ G2/G3: P < 0.05^*^
| | | | Hyperactivity: G1: −7.0 ± 7.1 G2: −6.5 ± 8.5 G3: −4.8 ± 6.4 G1/BL: P = NS^*^ G2/BL: P = NS^*^ G3/BL: P = NS^*^ G1/G2: P = NS^*^ G1/G3: P = NS^*^ G2/G3: P = NS^*^ Adaptive behavior: VABS total score, mean change ± SD: G1: 2.9 ± 6.5 G2: 3.3 ± 6.3 G3: −1.4 ± 4.0 G1/G2: P = NS^*^ G1/G3: P = NS^*^ G2/G3: P < 0.05^*^ VABS daily living skills score, mean change ± SD: G1: 2.7± 6.2 G2: 3.1± 8.6 G3: −1.5 ± 6.6 G1/BL: P = NS^*^ G2/BL: P = NS^*^ G3/BL: P = NS^*^ G1/G2: P = NS^*^ G1/G3: P = NS^*^ G2/G3: P = NS^*^ Commonly occurring co- morbidities: CRS-R ADHD score, mean change ± SD: G1: −6.9 ± 8.0 G2: −6.7 ± 6.2 G3: −3.8 ± 7.1 G1/BL: P = NS^*^ G2/BL: P = NS^*^ G3/BL: P = NS^*^ G1/G2: P = NS^*^ G1/G3: P = NS^*^ G2/G3: P = NS^*^
| | | | Motor skills: PEP-R fine motor score, mean change ± SD: G1: 3.8 ± 19.5 G2: 3.7 ± 13.1 G3: −1.1 ± 15.1 G1/BL: P = NS^*^ G2/BL: P = NS^*^ G3/BL: P = NS^*^ G1/G2: P = NS^*^ G1/G3: P = NS^*^ G2/G3: P = NS^*^ PEP-R gross motor score, mean change ± SD: G1: 30.8 ± 25.0 G2: 13.3 ± 19.7 G3: 11.0 ± 26.0 G1/BL: P < 0.01^*^ G2/BL: P < 0.01^*^ G3/BL: P = NS^*^ G1/G2: P = NS^*^ G1/G3: P = NS^*^ G2/G3: P = NS^*^ PEP-R hand-eye coordination score, mean change ± SD: G1: 12.4 ± 16.4 G2: 5.0 ± 21.9 G3: −0.9 ± 18.9 G1/BL: P < 0.05^*^ G2/BL: P = NS^*^ G3/BL: P = NS^*^ G1/G2: P = NS^*^ G1/G3: P = NS^*^ G2/G3: P = NS^*^ VABS motor skills score, mean change ± SD: G1: −2.0 ± 11.6 G2: 3.2 ± 10.7 G3: −0.9 ± 10.3 G1/BL: P = NS^*^ G2/BL: P = NS^*^ G3/BL: P = NS^*^ G1/G2: P = NS^*^ G1/G3: P = NS^*^ G2/G3: P = NS^*^
| | | | Educational/cognitive/academic attainment: GARS developmental disturbance score, mean change ± SD: G1: 0 ± 1.1 G2: −0.2 ± 1.2 G3: 0.5 ± 1.5 G1/BL: P = NS^*^ G2/BL: P = NS^*^ G3/BL: P = NS^*^ G1/G2: P = NS^*^ G1/G3: P = NS^*^ G2/G3: P = NS^*^ PEP-R cognitive score, mean change ± SD: G1: 18.6 ± 17.4 G2: 13.9 ± 16.0 G3: 5.9 ± 14.3 G1/BL: P < 0.01^*^ G2/BL: P < 0.01^*^ G3/BL: P = NS^*^ G1/G2: P = NS^*^ G1/G3: P = NS^*^ G2/G3: P = NS^*^ Harms: NR Modifiers: Age at intake

Comments:

* ANCOVA with age and baseline GARS total score as covariates.

Remington et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Remington et al., 2007 Country: UK Practice setting: Academic Intervention setting: Home, school, clinic Enrollment period: NR Funding: UK Health Foundation Author industry relationship disclosures: NR Design: Cohort, prospective | Intervention: Home-based early intervention for two years, 25.6 ± 4.8 hours/week (range 18.4–34.0 hours); one-on-one intervention provided by parents and 3–5 trained tutors; programs used discrete trial training and incorporated generalization procedures (specific programming individualized for each child), participants were identified based on parent preference for EIBI (funded either publicly n=13 or purchased privately n=10) Controls had local education authorities’ standard treatment for two years; in general not intensive or delivered one-to-one Assessments: Performance-based tests administered at family home, parents mailed questionnaires, telephone interviews using VABS approximately 1 week prior to the children’s 60 minute assessment visits at 3 time points (baseline, 1 and 2 year follow-up); ADI administered by first author, ESCS, BSID or Stanford Binet, and RDLS were administered by a Master’s level psycho-metrician Groups: G1: EIBI intervention G2: treatment as usual through public funds Provider: Parents and trained tutors, supervised by more experienced behavior analysts, in some cases a consultant with PhD experience in behavior analysis | Inclusion criteria:; - Autism diagnosis from ADI-R; - Previously diagnosed with autism by an independent clinician, or suspected autism diagnosis; - Age 30–42 months at enrollment; - Children lived in the family home; Exclusion criteria:; - Other chronic or serious medical conditions that would interfere with consistency of intervention; Age, months ± SD: G1: 35.7 ± 4.0 G2: 38.4 ± 4.4 G1/G2: P < 0.05 Mental age: See baseline measures Gender: NR Race/ethnicity: NR SES: University education, maternal, n (%): G1: 10/23 (43) G2: 4/21 (19) Household income: NR Mother working, n (%): Full time: G1: 0 G2: 0 Part time: G1: 7 (30.4) G2: 7 (33.3) Fathers (living in the family home) working, n (%): Full time: G1: 19/20 (95) G2: 17/20 (85) Part time: G1: 0 G2: 1/20 (5) Diagnostic approach: Referral | Overall ratings: DBC total score, mean ± SD: Maternal report: G1: 50.26 ± 22.75 G2: 67.81 ± 18.77 Paternal report: G1: 46.67 ± 22.15 G2: 57.57 ± 15.67 DBC autism score, mean ± SD: Maternal report: G1: 22.22 ± 9.54 G2: 31.14 ± 9.22 Paternal report: G1: 22.33 ± 9.92 G2: 26.29 ± 8.90 ASQ score, mean ± SD: Maternal report: G1: 19.26 ± 4.93 G2: 21.14 ± 5.47 Paternal report: G1: 20.88 ± 4.54 G2: 21.07 ± 6.41 Social skills: NCBRF positive social behavior score, mean ± SD: Maternal report: G1: 10.57 ± 4.24 G2: 9.29 ± 3.47 Paternal report: G1: 8.94 ± 3.47 G2: 8.73 ± 3.67 Communication/language: ESCS joint attention score, mean ± SD: Initiating: G1: 3.33 ± 4.40 G2: 3.63 ± 4.92 Responding: G1: 5.29 ± 3.62 G2: 5.94 ± 3.91 Reynell verbal comprehension score obtained, n: G1: 4 G2: 3 G1/G2: P = NS | Overall ratings: DBC total score, mean ± SD: Maternal report: G1: 44.70 ± 24.20 G2: 60.62 ± 24.72 Paternal report: G1: 45.19 ± 20.94 G2: 55.20 ± 19.44 DBC autism score, mean ± SD: Maternal report: G1: 18.91 ± 10.29 G2: 26.76 ± 11.21 Paternal report: G1: 19.50 ± 8.80 G2: 24.00 ± 11.60 ASQ score, mean ± SD: Maternal report: G1: 15.96 ± 5.63 G2: 19.29 ± 7.22 Paternal report: G1: 19.88 ± 6.16 G2: 19.47 ± 7.46 Social skills: NCBRF positive social behavior score, mean ± SD: Maternal report: G1: 15.30 ± 4.69 G2: 11.86 ± 4.84 G1/G2: P = 0.004 Paternal report: G1: 12.60 ± 4.06 G2: 11.20 ± 5.19 G1/G2: P = 0.053 Communication/language: ESCS joint attention score, mean ± SD: Initiating: G1: 11.76 ± 9.41 G2: 11.19 ± 13.86 G1/G2: P = NS Responding: G1: 11.29 ± 3.47 G2: 10.06 ± 4.99 G1/G2: P < 0.05
| Measure of treatment fidelity reported: No Co-interventions held stable during treatment: Yes Concomitant therapies, n (%): Baseline: Speech therapy: G1: 15 (65) G2: 12 (57) Dietary intervention: G1: 11 (48) G2: 3 (14) Prescription medications: G1: 1 (4) G2: 1 (5) Vitamin injection or high-dose vitamins: G1: 6 (26) G2: 0 Homeopathic intervention: G1: 5 (22) G2: 5 (24) 12 month follow-up: In mainstream school: G1: 13 (57) G2: 6 (48) Special needs school: G1: 0 G2: 9 (43) Mixed school: G1: 0 G2: 2 (10) TEACHH principles in school settings: G1: 2 (9) G2: 8 (38) PECS: G1: NR G2: 14 (67) Sign language/Makaton: G1: NR G2: 5 (24) Speech therapy: G1: 5 (22) G2: 14 (67) Dietary intervention: G1: 14 (61) G2: 4 (19) Prescription medications: G1: 4 (17) G2: 5 (24) | Diagnostic tool/method: ADI-R Diagnostic category, n (%): Autism : 44 (100) PDD-NOS: NR Aspergers: NR Other characteristics: NR | Reynell expressive language score obtained, n: G1: 2 G2: 1 G1/G2: P = NS Adaptive behavior: VABS score, mean ± SD: Composite: G1: 114.78 ± 26.89 G2: 113.57 ± 29.78 Communication: G1: 23.52 ± 11.35 G2: 21.62 ± 10.81 Daily living skills: G1: 24.13 ± 7.49 G2: 25.43 ± 10.56 Social skills: G1: 29.57 ± 6.65 G2: 28.29 ± 7.48 Motor skills: G1: 37.57 ± 6.37 G2: 38.24 ± 7.06 Educational/cognitive/academic attainment: IQ, Bayley and SB- IV, mean ± SD: G1: 61.43 ± 16.43 G2: 62.33 ± 16.64 Mental age, months ± SD: G1: 22.04 ± 6.89 G2: 23.71 ± 6.00 | Reynell verbal comprehension score obtained, n: G1: 21 G2: 11 G1/G2: P < 0.005 Reynell expressive language score obtained, n: G1: 21 G2: 10 G1/G2: P < 0.005 Adaptive behavior: VABS score, mean ± SD: Composite: G1: 202.83 ± 61.98 G2: 182.86 ± 58.89 Communication: G1: 54.74 ± 24.43 G2: 46.00 ± 24.51 Daily living skills: G1: 50.22 ± 16.46 G2: 44.67 ± 16.99 G1/G2: P < 0.05 Social skills: G1: 43.52 ± 15.94 G2: 41.48 ± 14.52 Motor skills: G1: 54.35 ± 9.12 G2: 50.71 ± 8.21 G1/G2: P < 0.05 Educational/cognitive/academic attainment: IQ, Bayley and SB-IV, mean ± SD: G1: 73.48 ± 27.28 G2: 60.14 ± 27.76 G1/G2: P < 0.01 Mental age, months ± SD: G1: 44.39 ± 16.39 G2: 38.00 ± 17.44 G1/G2: P < 0.01
| Vitamin injection or high- dose vitamins: G1: 10 (44) G2: 1 (5) Homeopathic intervention: G1: 2 (9) G2: 1 (5) 24 month follow-up: In mainstream school: G1: 17 (74) G2: 10 (48) Special needs school: G1: 5 (22) G2: 11 (52) TEACHH principles in school settings: G1: 3 (13) G2: 11 (52) PECS: G1: NR G2: 16 (76) Sign language/Makaton: G1: NR G2: 10 (48) Speech therapy: G1: 6 (26) G2: 10 (48) Dietary intervention: G1: 12 (52) G2: 6 (29) Prescription medications: G1: 1 (4) G2: 4 (19) Vitamin injection or high- dose vitamins: G1: 7 (30) G2: 1 (5) Homeopathic intervention: G1: 1 (4) G2: 1 (5) N at enrollment: G1: 23 G2: 21 N at follow-up: G1: 23 G2: 21 | | | Harms: NR Modifiers: In G1, 6 improved most on IQ tests (more than 23.94 points) vs. 6 whose IQ scores decreased: improved IQ associated with higher IQ, higher MA, higher VBS composite, communication, and social skills scores, lower vineland motor skills scores, more behavior problems on both maternal and paternal DBC, more autism symptoms on DBC, fewer intervention hours in year two
Author: Rickards et al., 2007 Country: Australia Practice setting: Academic Intervention setting: Clinic (child development and early intervention center) Enrollment period: May 2000 to December 2003 Funding: Murdoch Children’s Research Institute and the Jack Brockhoff Foundation Author industry relationship disclosures: NR Design: RCT | Intervention: Home-based program: 1 of 2 specialist preschool teachers visited each family weekly for 1–1.5 hours for 12 months. Time was spent discussing protocols developed at the centers, and developing new goals and strategies as needed. Included parent training and adapting home environment for the needs of the child. Addressed daily living skills, how to respond to behavior, how to provide choices. Center-based program: children in both the home- based program and control groups participated in one of two center- based programs. This consisted of 5 hours spread over two weekly sessions and included an individualized program for each child determined by the child’s developmental level, learning style, and interests. Training techniques included chaining, variety, repetition, sequencing, and reward systems. The major principle was to learn through play; communication systems (PECS), behavior modification techniques, speech and OT were provided as needed. Assessments: Baseline and 13 months (mean for both groups). Cognitive development either by BSID-II or by WPPSI-R Adaptive behavior by VABS parent interview Bayley Behavior Rating Scale by psychologist | Inclusion criteria:; - Delays in two or more areas of development based on play observations, parental interview, and information supplied by referring agency; Exclusion criteria:; - Diagnosis of cerebral palsy; - Families with inadequate English language skills; Age, months ± SD: G1: 44.6 ± 6.1 G2: 43.1 ± 6.5 Mental age: NR Gender, n (%): Male: G1: 24 (80) G2: 23 (79) Female: G1: 6 (20) G2: 6 (21) Race/ethnicity: NR SES: Maternal education < 12 years, n (%): G1: 14 (48.3) G2: 14 (50) Social status, Daniel Scale score, n (%): High (1–4): G1: 9 (30) G2: 11 (37.9) Low (4.1–7.0): G1: 21 (70) G2: 18 (62.1) Diagnostic approach: In Study Diagnostic tool/method: DSM-IV or ADI-R & ADOS Diagnostic category, n (%): ASD: G1: 18 (60) G2: 21 (72.4) Developmental delay: G1: 7 (23.3) G2: 2 (6.9) | Educational/cognitive/academic attainment: IQ score, mean ± SD: G1: 60.2 ± 20 G1a: 55.7 ± 22.1 G1b: 67 ± 14.4 G2: 60.6 ± 21.8 G2a: 52.9 ± 18.3 G2b: 80.8 ± 17.4 G1/G2: P = NS Problem behavior: Behavior Rating Scale score, mean ± SD G1: 98 ± 17.1 (n=29) G2: 98.3 ± 13.4 (n=28) G1/G2: P = NS Behavior Screening Questionnaire, mean ± SD: G1: 11.3 ± 4.9 G2: 9.6 ± 4.4 (n=28) G1/G2: P = NS Preschool Behavior Checklist score, mean ± SD: G1: 19.2 ± 10.4 (n=27) G1a: 22.1 ± 11 (n=16) G1b: 15 ± 8.2 (n=11) G2: 17.4 ± 10.8 (n=26) G2a: 22 ± 9.7 (n=18) G2b: 7.1 ± 3.4 (n=8) G1/G2: P = NS Adaptive behavior: VABS composite score, mean ± SD: G1: 61.2 ± 18.8 G2: 55 ± 14.6 (n=28) G1/G2: P = NS | Educational/cognitive/academic attainment: IQ score, mean ± SD: G1: 64.9 ± 22.2 G1a: 57.2 ± 21.9 G1b: 76.4 ± 17.9 G2: 57.1 ± 22.4 G2a: 48.6 ± 17.5 G2b: 79.4 ± 18.8 G1+G2/BL: P = NS G1/G2: P = 0.007 G1a/BL: P = NS G1b/BL: P = NS G2a/BL: P = NS G2b/BL: P = NS G1a/G2a: P = 0.09 G1b/G2b: P = 0.08 Change in IQ, n: Improved: G1: 12 G2: 3 No change: G1: 10 G2: 16 Deteriorated: G1: 8 G2: 10 No change: G1: 10 G2: 16 G1/G2: P = 0.03 Problem behavior: Behavior Rating Scale score, mean ± SD G1: 105.8 ± 13.2 (n=29) G2: 100.8 ± 11.2 (n=28) G1+G2/BL: P = 0.01 G1/G2: P = NS
| Behavior Screening Questionnaire competed by parents Preschool Behavior Checklist completed by teachers QRS-F stress and family scales completed by parents/caregivers Groups: G1: home-based program G2: controls Ga: autism Gb: developmental and language delay Provider: Multidisciplinary team including psychologist, teacher and parent Measure of treatment fidelity reported: No Co-interventions held stable during treatment: Yes Concomitant therapies, n (%): Speech therapy: G1: 6 (20) G2: 10 (34.5) N at enrollment: G1: 30 G1a: 18 G1b: 12 G2: 29 G2a: 21 G2b: 8 N at follow-up: G1: 30 G2: 29 | Language delay: G1: 5 (16.7) G2: 6 (20.7) Other characteristics: NR | | Behavior Screening Questionnaire, mean ± SD: G1: 8 ± 5.1 G2: 8.1 ± 3.8 (n=28) G1+G2/BL: P = 0.0004 G1/G2: P = NS Preschool Behavior Checklist score, mean ± SD: G1: 12 ± 8.5 (n=27) G1a: 13.7 ± 8.3 (n=16) G1b: 9.6 ± 8.6 (n=11) G2: 17.7 ± 8.2 (n=26) G2a: 21.2 ± 6.7 (n=18) G2b: 10 ± 5.6 (n=8) G1+G2/BL: P = 0.0014 G1/G2: P = 0.007 G1a/BL: P = 0.02 G1b/BL: P = NS G2a/BL: P = NS G2b/BL: P = NS G1a/G2a: P = 0.054 G1b/G2b: P = 0.02 Change in PBCL: Improved: G1: 14 G2: 8 No change: G1: 9 G2: 12 Deteriorated: G1: 4 G2: 7 G1/G2: P = NS Changed from severe behavior problem classification to normal range, n: G1: 11/18 G2: 1/17
| | | | Adaptive behavior: VABS composite score, mean ± SD: G1: 64.3 ± 20.4 G2: 59.2 ± 19.7 (n=28) G1+G2/BL: P = 0.01 G1/G2: P = NS Harms: NR Modifiers: No girl in G1 showed any improvement in either IQ/PBCL; in G2, only 1 improved on IQ and 2 improved on PBCL. Boys IQ improved (P = 0.003) and PBCL improved (P = 0.03) Improvement in IQ significantly associated in G1 with low SES status (P = 0.04), age < 42 months (P = 0.001), and family stress QRS-F >160 (P = 0.02). Improvement in PBCL significantly associated with age < 42 months (P = 0.04) in G1 but not in G2.

Silva et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Silva et al., 2007 Country: US Practice setting: Academic Intervention setting: Clinic and home Enrollment period: August 2005 Funding: Spirit Mountain community fund & Brigid Kildare Author industry relationship disclosures: NR Design: RCT with continuation Note: See related papers Silva et al., 2008, 2009 {#58:#5051} | Intervention: Qigong Massage movements (Cignolini methodology) Treatment given twice weekly for two 5 week periods with 5 weeks in-between by trained practitioner; parent administers the same treatment at least once daily for 5 months Children stratified into 3 groups according to Battele Developmental Inventory cognitive scores then randomly assigned to treatment and control within each cognitive group All children attended pre- school classrooms 2–4 times/week for 2 hours at the Willamette Education Service District Assessments: Principal author provided initial evaluation of child, including administering Batelle Developmental Inventory Blinded examiners administered VABS and ABC tests and parents completed a sensory profile questionnaire pre- and post-treatment; exit interview with parents administered post- treatment. Several treatment visits and the exit interview were videotaped. Groups: G1: Cignolini method G2: controls Provider: Parent and trained practitioner Measure of treatment fidelity reported: NR | Inclusion criteria:; - Formal diagnosis of uncomplicated autism according to DSM-IV; - Age up to 6 years; - Parental commitment to give massage every day for 5 months and get the child to the clinic to get prescription from the doctor 20 times; - Willingness of the parent not to try any new treatments while in this study; Exclusion criteria:; - Children with other neurological conditions such as seizures; - Chronic medication; Age, years (range): 4.83 (3–6) Mental age: NR Gender, n (%): Male: 13 (86.7) Female: 2 (13.3) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In study Diagnostic tool/method: DSM-IV by medical specialists Diagnostic category, n (%): Autism: 15 (100) Other characteristics: NR | Social skills: VABS socialization, score, mean: G1: 29.8 G2: 24.7 Communication/language: VABS receptive language score, mean: G1: 33.8 G2: 23.6 VABS expressive language score, mean: G1: 31.5 G2: 24.4 Adaptive behavior: ABC score, mean: G1: 71.3 G2: 87.7 VABS daily living skills, mean: G1: 28.8 G2: 24.1 Motor skills: VABS gross motor skills score, mean: G1: 37.5 G2: 33.4 VABS fine motor skills, mean: G1: 36 G2: 29 Sensory: Sensory profile score, mean: Total (items A-N): G1: 16.2 G2: 15.7 Processing (items A-F): G1: 7.2 G2: 7.1 Modulation (items G-K): G1: 5.3 G2: 5 | Social skills: VABS socialization, score, mean change: G1: 10 G2: 4.7 G1/G2: P = 0.04 Communication/language: VABS receptive language score, mean change: G1: 8.3 G2: 10.6 G1/G2: P = NS VABS expressive language score, mean change: G1: 8.9 G2: 6.7 G1/G2: P = NS Adaptive behavior: ABC score, mean change: G1: −13.3 G2: −24.3 G1/G2: P = NS VABS daily living skills, mean change: G1: 9.8 G2: 0.9 G1/G2: P = 0.02 Motor skills: VABS gross motor skills score, mean change: G1: 6.5 G2: 0.9 G1/G2: P = NS VABS fine motor skills, mean change: G1: 8.8 G2: 7.6 G1/G2: P = NS
| Co-interventions held stable during treatment: See inclusion criteria Concomitant therapies, n (%): Speech therapy: 4/15 (26) N at enrollment: G1: 8 G2: 7 N at follow-up: G1: 13^*^ G2: 7 | | Behavioral/emotional abnormality (items L-N): G1: 3.6 G2: 3.6 Factor scale (factors 1–8): G1: 8.5 G2: 8.7 | Sensory: Sensory profile score, mean change: Total (items A-N): G1: −5.4 G2: 2.7 G1/G2: P = 0.01 Processing (items A-F): G1: −2.4 G2: 1 G1/G2: P = 0.01 Modulation (items G-K): G1: −1.9 G2: 1 G1/G2: P = 0.02 Behavioral/emotional abnormality (items L-N): G1: −1.1 G2: 0.7 G1/G2: P = 0.02 Factor scale (factors 1–8): G1: −3.1 G2: 1.4 G1/G2: P = 0.02 Medical: Improvement in bowel and sleep abnormalities, n: G1: 8/8 G2: 0 Harms: NR Modifiers: NR

Comments:

* The authors state that because the treatment was beneficial, after the RCT phase the 7 controls were offered the treatment. One child could not participate because of his mother’s severe health problems, and one child began treatment but moved from the area after completing only 9 weeks. The pre- and post-treatment measures of 5 controls in the continuation phase are included in the baseline and outcome measures reported (the authors do not report the measures separately for the original treatment group and continuation group).

** The authors do not report standard deviations or standard errors, but do report the Kruskal Wallace H statistic.

Sofronoff et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Sofronoff et al., 2007 Country: Australia Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: Apex Autism Trust Foundation Author industry relationship disclosures: NR Design: RCT | Intervention: Cognitive Behavior Therapy for Anger Management, sessions included exploration of different feelings, methods for “fixing” the feelings, relaxation techniques, recruiting help to restore positive feelings, and social stories; 2 hours per week for 6 weeks Assessments: Therapists assessed children individually with WISC; child completed anger measures (Dylan, What makes me angry); parents completed Children’s Inventory of Anger Groups: G1: intervention G2: waitlist control Provider: Postgraduate students from clinical psychology program trained in the technique in a one-day workshop Measure of treatment fidelity reported: Yes Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 24 G2: 21 N at follow-up: G1: 24 G2: 21 | Inclusion criteria:; - Primary diagnosis of Asperger syndrome from a pediatrician and inter-view with parents based on DSM-IV criteria and CAST; Exclusion criteria:; - See inclusion criteria; Age, years ± SD (range): G1: 10.79 ± 1.12 (9.8–13.6) G2: 10.77 ± 0.87 (10.1–13.0) Mental age: IQ (WISC-III), mean ± SD (range): G1: 105.24 ± 22.3 (95–132) G2: 108.7 ± 21.6 (101–127) Gender, n (%): Male: G1: 23 (96) G2: 20 (95) Female: G1: 1 (4) G2: 1 (5) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral and in-study confirmation Diagnostic tool/method: Semi-structured interview and CAST based on DSM-IV criteria Diagnostic category, n (%): Asperger’s: 45 (100) Other characteristics, n (%): ADHD diagnosis: G1: 11 (46) G2: 9 (43) | Problem behavior: Children’s Inventory of Anger score, mean: Total: G1: 108.7 G2: 109.1 Frustration: G1: 28.6 G2: 28.9 Physical aggression: G1: 25.1 G2: 24.1 Peer relationships: G1: 23.8 G2: 24.4 Authority relationships: G1: 29 G2: 28 Parent monitoring of instances of anger, mean ± SD: G1: 8.7 ± 4.4 G2: 7.6 ± 4.3 Parent monitoring of anger management, mean ± SD:^*^ Parent confidence: G1: 4.3 ± 2.2 G2: 4.9 ± 2 Child confidence: G1: 2.7 ± 1.7 G2: 2.9 ± 2 | Problem behavior: Children’s Inventory of Anger score, mean: Total: Post-treatment: G1: 100.7 G2: 108.1 G1/BL: P < 0.0001 G2/BL: P = NS 6 week follow-up: G1: 97.4 G2: 108.1 G1/BL: P < 0.001 G2/BL: P = NS Frustration: Post-treatment: G1: 26.1 G2: 28.4 G1/BL: P < 0.0001 G2/BL: P = NS 6 week follow-up: G1: 24.7 G2: 28.4 G1/BL: P < 0.0001 G2/BL: P = NS Physical aggression: Post-treatment: G1: 25.2 G2: 23.0 G1/BL: P = NS G2/BL: P = NS 6 week follow-up: G1: 25.4 G2: 28.6 G1/BL: P = NS G2/BL: P = NS Peer relationships: Post-treatment: G1: 22.3 G2: 23.4 G1/BL: P < 0.05 G2/BL: P = NS
| | | | 6 week follow-up: G1: 21.7 G2: 23.4 G1/BL: P < 0.05 G2/BL: P = NS Authority relationships: Post-treatment: G1: 26.7 G2: 28.3 G1/BL: P < 0.0001 G2/BL: P = NS G1/G2: P < 0.02 6 week follow-up: G1: 25.7 G2: 28.3 G1/BL: P < 0.05 G2/BL: P = NS Parent monitoring of instances of anger, mean ± SD: Post-treatment: G1: 3.7 ± 3.9 G2: 7.9 ± 5.1 G1/BL: P < 0.0001 G2/BL: P = NS G1/G2: P < 0.005 6-week follow-up: G1: 3.2 ± 3.9 G2: 7.9 ± 5.1 G1/BL: P < 0.0001 G2/BL: P = NS Parent monitoring of anger management, mean ± SD:^*^ Parent confidence: Post-treatment: G1: 6 ± 1.6 G2: 5.2 ± 2.1 G1/BL: P < 0.001 G2/BL: P = NS 6-week follow-up: G1: 6.1 ± 1.9 G2: 5.2 ± 2.1 G1/BL: P < 0.001 G2/BL: P = NS
| | | | Child confidence Post-treatment: G1: 4.1 ± 1.7 G2: 2.9 ± 2.2 G1/BL: P < 0.0001 G2/BL: P = NS 6-week follow-up: G1: 5.2 ± 1.9 G2: 2.9 ± 2.2 G1/BL: P < 0.0001 G2/BL: P = NS G1/G2: P < 0.0001 Harms: NR Modifiers: NR

Comments:

* scale of 1–10: 1 not confident at all, 10 extremely confident

Solomon et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Solomon et al., 2007 Country: US Practice setting: Academic Intervention setting: Home Enrollment period: October 2000 to February 2002 Funding: Fee for service and foundation grant Author industry relationship disclosures: NR Design: Case series, prospective | Intervention: PLAY parent training program: trained consultants visit home monthly for 3–4 hours to teach parents intensive 1:1 play-based services (modeling, coaching, video assessment, written objectives). Parents attended 1 day workshop by lead author on play-based DIR methods. Assessments: FEAS, clinical rating by home consultant at baseline and 1 year, family log of PLAY hours at home, and client satisfaction survey Videotaped assessments and half-day/month home visits Groups: G1: PLAY intervention Provider: Three trained home consultants: one MSW and two recreational therapists Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies, n (%): Early intervention (under age 3, about 2 hours/wk): 12 (18) Special education preschool programs (age 3 and older): 56 (82) N at enrollment: G1: 74 N at follow-up: G1: 68 | Inclusion criteria:; - Diagnosis of autistic disorder, PDD-NOS/Asperger syndrome according to DSM-IV criteria; - Between 18 months and 6 years old at time of diagnosis; Exclusion criteria:; - Live more than 60 miles from Ann Arbor, MI; - Participation in other intensive intervention more than 10 hrs/week with 1:1 or 1:2 teacher to pupil ratio; - Severe medical disability; Age, years (SE) (range): 3.7 (0.2) (2–7) Mental age: NR Gender, n (%): Male: 51 (75) Female: 17 (25) Race/ethnicity, n (%): White: 65 (96) African-American: 3 (4) SES: Parents with bachelor’s degrees or above, %: 70 (approximately) Household income: NR Diagnostic approach: Referral Diagnostic tool/method: DSM-IV Diagnostic category, n: Severe autism: 10 Moderate autism: 22 Mild Autism: 18 PDD-NOS: 14 Aspergers: 3 Down’s syndrome: 1 Seizure disorders: 2 Other characteristics: Mother’s age, mean (range): 37 (28–49) Father’s age, mean (range): 38 (27–53) | Emotional: FEAS score, caregivers, mean: G1: 86 FEAS score, children, mean: G1: 38 Scaled FEAS score, children, mean: G1: 3.6 Clinical rating, mean: G1: 2.5 | Emotional: FEAS score, caregivers, mean: G1: 86 G1/BL: P = NS FEAS score, children, mean: G1: 45 G1/BL: P ≤ 0.0001 Scaled FEAS score, children, mean: G1: 4.5 G1/BL: P ≤ 0.0001 Clinical rating, mean: G1: 4.2 G1/BL: P ≤ 0.0001 Good to very good functional development progress, %:^*^ FEAS scores: 45.5 Clinical rating: 85.3 Family survey result, n: Very satisfied: 35/50 Somewhat satisfied: 10/50 Unsatisfied: 5/50 Harms: NR Modifiers: No significant relationship found between initial ASD severity and FEAS total or scaled scores. Marginal association between hours/week of intervention and lower scaled FEAS scores (P = 0.09).
| | Married, %: 91 Number of siblings, mean (range): 0.75 (0–3)

Comments:

* Clinicians over-rated improvements compared to FEAS scores.

Tsang et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Tsang et al., 2007 Country: China Practice setting: Academic Intervention setting: School Enrollment period: NR Funding: Providence Foundation Limited; Committee on Conference and Research Grants, The University of Hong Kong; Research Grants Council of the Hong Kong Special Administrative Region Author industry relationship disclosures: NR Design: Prospective cohort | Intervention: Chinese version of TEACCH for 12 months, 7 hours/day, 5 days/week vs. varied non-TEACCH full-time training, 5 days/week Assessments: CPEP-R, Merrill Palmer Scale and HKBABS administered; context NR Groups: G1: TEACCH training G2: varied non-TEACCH Provider: NR Measure of treatment fidelity reported: No Co-interventions held stable during treatment: Yes Concomitant therapies: Individualized or group treatment by speech, occupational or physiotherapist as needed; numbers NR N at enrollment: G1: 18 G2: 16 N at 6 month follow-up: G1: 18 G2: 16 N at 12 month follow-up: G1: 18 G2: 2 | Inclusion criteria:; - Formally diagnosed with PDD including autistic disorder and PDD-NOS by DSM-IV; - No prior exposure to structured teaching, TEACCH; - Randomly selected from preschool children with autism studying at Heep Hong Society (G1); - Recruited from Preschool Parents’ Association & Child Assessment Centres of the Department of Health (G2); Exclusion criteria:; - See inclusion criteria; Age, years ± SD (range): G1: 4.06 ± 0.53 (3–5) G2: 4.05 ± 0.73 (3–5) Mental age: See baseline measures Gender, n (%): Male: G1: 17 (94.4) G2: 12 (75) Female: G1: 1 (5.6) G2: 4 (25) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: See inclusion criteria Diagnostic tool/method: DSM-IV Diagnostic category: See inclusion creteria Other characteristics: IQ, mean ± SD: G1: 59.97 ± 11.10 G2: 74.22 ± 18.06 | Overall ratings: Merrill-Palmer raw score, mean ± SD: G1: 29.22 ± 15.98 G2: 49.62 ± 28.02 Merrill-Palmer mental age, mean ± SD: G1: 28.11 ± 6.21 G2: 36.06 ± 10.94 HKBABS sum of standard scores, mean ± SD: G1: 231.11 ± 22.99 G2: 290.69 ± 444.73 Educational/cognitive/academic attainment: CPEP-R score, mean ± SD: Cognitive performance: G1: 5.22 ± 2.65 G2: 10.50 ± 7.47 Cognitive verbal: G1: 1.11 ± 1.28 G2: 8.44 ± 7.55 Developmental scale total: G1: 45.44 ± 13.67 G2: 75.62 ± 32.03 Social skills: HKBABS total score, mean ± SD: Socialization: G1: 27.06 ± 8.33 G2: 48.81 ± 15.98 Communication/language: CPEP-R score, mean ± SD: Imitation: G1: 4.22 ± 3.10 G2: 8.19 ± 6.58 Perception: G1: 7.28 ± 2.56 G2: 8.88 ± 4.48 | Overall ratings: Merrill-Palmer raw scores, mean ± SD: 6 months: G1: 40.78 ± 16.79 G2: 59.75 ± 22.14 G1/BL: P ≤ 0.001 G2/BL: P ≤ 0.001 G1/G2: P = NS^*^ ANOVA: time (P ≤ 0.001) 12 months: G1: 48.00 ± 19.55 G1/6M: ≤ 0.01 ANOVA: time (P ≤ 0.001) Merrill-Palmer mental age, mean ± SD: 6 months: G1: 32.78 ± 6.30 G2: 40.12 ± 8.64 G1/BL: P ≤ 0.001 G2/BL: P ≤ 0.001 G1/G2: P = NS^*^ 12 months: G1: 35.44 ± 7.38 G1/6M: P ≤ 0.01 ANOVA: time (P ≤ 0.001)CPEP-R score, mean ± SD: HKBABS sum of standard scores, mean ± SD: 6 months: G1: 226.39 ± 31.38 G2: 315.19 ± 60.00 G1/BL: P = NS G2/BL: P ≤ 0.01 G1/G2: P ≤ 0.05^*^ 12 months: G1: 232.28 ± 31.86 G1/6M: P = NS ANOVA: time (P ≤ NS)
| | Ratio of mental retardation: limited intelligence or above: G1: 14:4 G2: 7:9 | HKBABS total score, mean ± SD: Communication: G1: 20.56 ± 9.40 G2: 66.62 ± 30.92 Adaptive behavior: HKBABS total score, mean ± SD: Daily living skills: G1: 42.33 ± 12.89 G2: 62.62 ± 24.42 Motor skills: CPEP-R score, mean ± SD: Fine motor: G1: 8.89 ± 1.97 G2: 9.50 ± 4.87 Gross motor: G1: 13.22 ± 2.88 G2: 12.87 ± 5.51 Eye-hand coordination: G1: 5.50 ± 2.20 G2: 7.06 ± 4.65 HKBABS total score, mean ± SD: Motor skills: G1: 49.89 ± 11.86 G2: 61.50 ± 12.20 | Educational/cognitive/academic attainment: Cognitive performance: 6 months: G1: 7.00 ± 3.16 G2: 13.19 ± 8.96 G1/BL: P ≤ 0.01 G2/BL: P = NS G1/G2: P = NS^*^ 12 months: G1: 8.28 ± 4.04 G1/6M: P = NS ANOVA: time (P ≤ 0.001) Cognitive verbal: 6 months: G1: 3.50 ± 3.15 G2: 11.12 ± 8.27 G1/BL: P ≤ 0.001 G2/BL: P = NS G1/G2: P = NS^*^ 12 months: G1: 5.00 ± 4.42 G1/6M: P ≤ 0.01 ANOVA: time (P ≤ 0.001) Developmental scale total: 6 months: G1: 56.89 ± 15.66 G2: 87.25 ± 30.68 G1/BL: P ≤ 0.001 G2/BL: P ≤ 0.001 G1/G2: P = NS^*^ 12 months: G1: 62.39 ± 17.80 G1/6M: P ≤ 0.05 ANOVA: time (P ≤ 0.001) Social skills: HKBABS total score, mean ± SD: Socialization: 6 months: G1: 29.61 ± 8.26 G2: 58.44 ± 19.10 G1/BL: P = NS G2/BL: P ≤ 0.01 G1/G2: P = NS^*^
| | | | 12 months: G1: 35.33 ± 12.09 G1/6M: P ≤ 0.01 ANOVA: time (P ≤ 0.001) Communication/language: CPEP-R score, mean ± SD: Imitation: 6 months: G1: 6.50 ± 3.48 G2: 9.37 ± 6.43 G1/BL: P ≤ 0.001 G2/BL: P = NS G1/G2: P = NS^*^ 12 months: G1: 7.22 ± 3.87 G1/6M: P = NS ANOVA: time (P ≤ 0.001) Perception: 6 months: G1: 8.89 ± 2.54 G2: 8.62 ± 5.52 G1/BL: P ≤ 0.001 G2/BL: P = NS G1/G2: P ≤ 0.05^*^ 12 months: G1: 9.39 ± 2.59 G1/6M: P = NS ANOVA: time (P ≤ 0.001) HKBABS total score, mean ± SD: Communication: 6 months: G1: 28.56 ± 12.37 G2: 83.25 ± 34.42 G1/BL: P ≤ 0.01 G2/BL: P ≤ 0.001 G1/G2: P = NS^*^ 12 months: G1: 40.11 ± 20.47 G1/6M: P ≤ 0.01 ANOVA: time (P ≤ 0.001)
| | | | Adaptive behavior: HKBABS total score, mean ± SD: Daily living skills: 6 months: G1: 46.67 ± 12.31 G2: 79.00 ± 23.45 G1/BL: P ≤ 0.05 G2/BL: P ≤ 0.001 G1/G2: P ≤ 0.001^*^ 12 months: G1: 58.56 ± 18.62 G1/6M: P ≤ 0.001 ANOVA: time (P ≤ 0.001) Motor skills: CPEP-R score, mean ± SD: Fine motor: 6 months: G1: 10.67 ± 1.61 G2: 9.69 ± 5.61 G1/BL: P ≤ 0.001 G2/BL: P = NS G1/G2: P ≤ 0.01^*^ 12 months: G1: 10.67 ± 1.61 G1/6M: P = NS ANOVA: time (P ≤ 0.001) Gross motor: 6 months: G1: 14.44 ± 2.33 G2: 12.62 ± 7.09 G1/BL: P ≤ 0.01 G2/BL: P = NS G1/G2: P ≤ 0.05^*^ 12 months: G1: 14.44 ± 2.38 G1/6M: P = NS ANOVA: time (P ≤ 0.05) Eye-hand coordination: 6 months: G1: 6.50 ± 2.50 G2: 9.44 ± 5.81 G1/BL: P ≤ 0.05 G2/BL: P = NS G1/G2: P = NS^*^
| | | | 12 months: G1: 7.39 ± 3.05 G1/6M: P ≤ 0.05 ANOVA: time (P ≤ 0.001) HKBABS total score, mean ± SD: Motor skills: 6 months: G1: 53.94 ± 10.78 G2: 65.62 ± 12.02 G1/BL: P ≤ 0.05 G2/BL: P ≤ 0.001 G1/G2: P = NS^*^ 12 months: G1: 59.11 ± 10.05 G1/6M: P ≤ 0.001 ANOVA: time (P ≤ 0.001) Harms: NR Modifiers: NR

Comments:

* after controlling for age, IQ and baseline scores

Vorgraft et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Vorgraft et al., 2007 Country: Israel Practice setting: Academic Intervention setting: Residential and home Enrollment period: 1997 to 1999 Funding: NR Author industry relationship disclosures: NR Design: Case series, retropective | Intervention: Mifne treatment: family attends a residential treatment facility for 3 weeks; therapy is provided together and separately for each family member, followed by intensive home care for 6–18 months, and a gradual integration into nursery. Reciprocal play therapy attempts to gradually introduce social interactions to the child by using the child’s lead. Assessments: Assessments by trained raters of videotapes of child in home and clinic (Mifne) settings CARS, SBRS Groups: G1: Mifne treatment Ga: baseline CARS total score ≤ 27 Gb: baseline CARS total score ≥ 28 Provider: OT, physiotherapists, psychologists, social workers, and speech therapists trained for 1.5 years and accredited Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 23 G1a: 14 G1b: 9 N at follow-up: G1: 23 | Inclusion criteria:; - Children with PDD treated at the Mifne Institute for whom full documentation was available; - DSM-IV diagnosis by consultant child and adolescent psychiatrists; - Diagnosis confirmation by two senior clinicians on the study team after chart review; Exclusion criteria:; - See inclusion criteria; Age, months ± SD (range): 42.8 ± 11.4 (38–49) Mental age: NR Gender, n (%): Male: 15 (65) Female: 8 (35) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In study Diagnostic tool/method: Based on DSM-IV Diagnostic category, n (%): Autistic disorder: 14 (61) PDD-NOS: 9 (39) Other characteristics, n (%): Intellectual impairment: 2 (9) Specific developmental language disorder: 1 (4) | Overall ratings: CARS score, home video, mean ± SD: Total: G1: 27.7 ± 6.1 Emotional response: G1: 2 ± 0.8 Fearful and nervous response: G1: 1.8 ± 0.0 Overall impression: G1: 2.9 ± 0.7 CARS score, Mifne video, mean ± SD: Total: G1: 29.7 ± 7.1 Emotional response: G1: 2.4 ± 0.7 Fearful and nervous response: G1: 1.6 ± 0.9 Overall impression: G1: 2.7 ± 0.7 SBRS score, home video, mean ± SD: Total: G1: 46 ± 8.1 Awareness of others’ emotional states: G1: 3.3 ± 0.7 Mutuality: G1: 3.7 ± 0.5 Overall impression: G1: 3 ± 0.8 SBRS score, Mifne video, mean ± SD: Total: G1: 48.5 ± 7.9 Awareness of others’ emotional states: G1: 3.5 ± 0.6 Joint positive emotional experiences: G1: 3.4 ± 0.7 | Overall ratings: CARS score, home video, mean ± SD: Total: G1: 24.5 ± 5.3 G1/BL: P = NS Emotional response: G1: 1.8 ± 0.8 G1/BL: P < 0.05 Fearful and nervous response: G1: 1 ± 0.0 G1/BL: P < 0.05 Overall impression: G1: 2.5 ± 0.8 G1/BL: P < 0.05 CARS total score, home video, mean change ± SD: G1a: −0.27 ± 3.6 G1b: 7.56 ± 7.8 G1a/BL: P = NS G2a/BL: P < 0.05 CARS score, Mifne video, mean ± SD: Total: G1: 26.7 ± 6 G1/BL: P < 0.01 Emotional response: G1: 2 ± 0.4 G1/BL: P < 0.05 Fearful and nervous response: G1: 1.1 ± 0.3 G1/BL: P < 0.05 Overall impression: G1: 1.7 ± 0.5 G1/BL: P < 0.05 CARS total score, Mifne video, mean change ± SD: G1a: 0.25 ± 4.8 G1b: 5.82 ± 6.3 G1a/BL: P = NS G2a/BL: P < 0.01
| | | Emotional availability: G1: 3.1 ± 0.9 Reactions to social initiative: G1: 3.1 ± 0.8 Overall impression G1: 3 ± 0.9 | SBRS score, home video, mean ± SD: Total: G1: 41.2 ± 7.6 G1/BL: P < 0.01 Awareness of others’ emotional states: G1: 2.8 ± 0.9 G1/BL: P < 0.05 Mutuality: G1: 3.1 ± 0.7 G1/BL: P < 0.05 Overall impression: G1: 2.5 ± 0.8 G1/BL: P < 0.05 SBRS score, home video, mean change ± SD: G1a: 1.27 ± 4.8 G1b: 9.11 ± 8.3 G1a/BL: P = NS G2a/BL: P < 0.01 SBRS score, Mifne video, mean ± SD: Total: G1: 44 ± 1.4 G1/BL: P < 0.01 Awareness of others’ emotional states: G1: 3 ± 0.8 G1/BL: P < 0.05 Joint positive emotional experiences: G1: 2.8 ± 0.7 G1/BL: P < 0.05 Emotional availability: G1: 2.5 ± 0.7 G1/BL: P < 0.05 Reactions to social initiative: G1: 2.4 ± 0.7 G1/BL: P < 0.05
| | | | Overall impression: G1: 2.4 ± 0.7 G1/BL: P < 0.05 SBRS score, Mifne video, mean change ± SD: G1a: 2.92 ± 8.4 G1b: 6.27 ± 7.3 G1a/BL: P = NS G2a/BL: P < 0.05 Harms: NR Modifiers: NR

Wong et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Wong et al., 2007 Country: US Practice setting: Academic Intervention setting: School Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: Prospective case series Note: See related study Gulsrud et al. 2007{#2578}, Jahromi et a. 2009{#3615}, Kasari et al. 2008{#184}, and Kasari et al. 2006{#540} | Intervention: Targeted intervention for play skills focused on improving functional and symbolic play skills; targeted intervention for joint attention skills. Both interventions occurred daily for 30 minutes by trained interventionist: starting with Naturalistic I conditions at the table for approximately 5–8 minutes, followed by Naturalistic II floor conditions for approximately 20–25 minutes Assessments: Before start of treatment: MSEL, RDLS, SPA, ESCSA, M-CIA Groups: G1: play skills G2: joint attention Provider: Trained interventionist Measure of treatment fidelity reported: Yes Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 21 G2: 20 N at follow-up: G1: 21 G2: 20 | Inclusion criteria:; - Preschool-aged children with autism in early intervention program; - Staying in preschool program > 1 month and not involved in other educational programs; Exclusion criteria:; - Seizures; - On medication; - Associated sensory or physical disorders; - Comorbidity with other syndromes or diseases; Age, months ± SD: G1: 42.67 ± 6.92 G2: 43.2 ± 7.05 Mental age, months ± SD: G1: 24.55 ± 8.09 G2: 26.29 ± 8.71 Gender, n (%): Male: G1: 16 (76) G2: 15 (75) Female: G1: 5 (24) G2: 5 (25) Race/ethnicity, n (%): Caucasian: G1: 16 (76) G2: 16 (80) Hispanic: G1: 1 (5) G2: 0 Asian: G1: 2 (10) G2: 1 (5) Other: G1: 2 (10) G2: 3 (15) SES: Maternal education, n (%): High school: G1: 3 (14) G2: 0 Some college: G1: 3 (14) G2: 2 (10) Special training after high school: G1: 1 (5) G2: 0 | Communication/language: Developmental quotient, mean ± SD: G1: 58.90 ± 18.21 G2: 58.30 ± 17.18 Reynell developmental language age, months ± SD: Receptive language G1: 21.00 ± 9.75 G2: 20.55 ± 7.27 Expressive language: G1: 21.43 ± 7.59 G2: 20.60 ± 6.51 | Educational/cognitive/academic attainment: Days to performance mastery, mean: Naturalistic I conditions: G1: 3.24 G2: 5.32 G1/G2: P < 0.05 Naturalistic II conditions: G1: 5.2 G2: 6.3 G1/G2: P = NS Harms: NR Modifiers: Children with higher mental, receptive and expressive language age reached mastery criteria in fewer days (P < 0.05) Significant interaction effect between teaching method and child’s developmental quotient (P = 0.02) for Naturalistic II conditions. Significant interaction between teaching method & skill domain (F = 5.04, P = 0.03). G1 showed mastery in significantly fewer days than G2 in the Naturalistic I teaching environment.
| | Completed college: G1: 8 (38) G2: 12 (60) Graduate/professional training: G1: 6 (29) G2: 6 (30) Household income: NR Diagnostic approach: In Study Diagnostic tool/method: ADI-R, ADOS Diagnostic category, n (%): Autism: 41 (100) Other characteristics: NR

Comments: Most data is presented in graphs and figures rather than tables.

Zachor et al., 2007

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Zachor et al., 2007 Country: Israel Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: Israeli Ministry of Education Author industry relationship disclosures: NR Design: Prospective cohort Note: See related studies: Ben Itzchak et al. 2007, Zachor et al. 2007, Zachor et al. 2009, Ben Itzchak et al. 2007; the overlap among these is not clear | Intervention: Participants received either applied behavioral or eclectic treatment. Behavioral was 1-to-1 individualized treatment for 35 hrs/week addressing various skills such as imitation, receptive and expressive language, joint attention, non-verbal communication, pre-academic skills, play, fine motor skills and adaptive living skills. Eclectic was small-group activities supervised by special education teacher, individual therapy with various therapists (i.e., speech and language, occupational and music therapies, and structured cognitive teaching; each provided 2 hr of individual, 1 hr of group therapy, and 1 hr of consultation to the team), and also included parent training to address problem behaviors. Assessments: Autism severity: ADI, ADOS Cognitive ability: BSID-II (pre-verbal children), SB-FE Groups: G1: behavioral G2: eclectic Provider: Special education teacher, speech and language therapists, occupational therapists, music therapists, behavior analysts Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR | Inclusion criteria:; - Met DSM-IV criteria for Autism/PDD-NOS; Exclusion criteria:; - Identified medical abnormalities, such as seizures, hearing deficiencies; Age, months (range): G1: 27.7 (22–34) G2: 28.8 (23–33) Mental age: NR Gender, n (%): Male: G1: 19 (95) G2: 18 (95) Female: G1: 1 (5) G2: 1 (5) Race/ethnicity, n (%): NR SES: Maternal education: NR Household income: NR Diagnostic approach: In Study Diagnostic tool/method: ADI Diagnostic category, n (%): Autism: G1: 19 (95) G2: 18 (95) ASD: G1: 1 (5) G2: 1 (5) Other characteristics: NR | Social skills: ADOS reciprocal social interaction score, mean ± SD: G1: 17.9 ± 6.2 G2: 16.3 ± 5.2 Communication/language: ADOS language and communication score, mean ± SD: G1: 13.8 ± 4.3 G2: 11.8 ± 4.3 | Overall ratings: ASD diagnostic category, n (%): Autism: G1: 11 (55) G2: 15 (79) ASD: G1: 5 (25) G2: 4 (21) Off spectrum: G1: 4 (20) G2: 0 G1/G2: P < 0.05 Social skills: ADOS reciprocal social interaction score, mean ± SD: G1: 11.1 ± 6.7 G2: 13.3 ± 4.8 G1/BL: P < 0.001 G2/BL: P < 0.05 G1/G2: P = 0.07 Communication/language: ADOS language and communication score, mean ± SD: G1: 7.2 ± 4.1 G2: 9.7 ± 3 G1/BL: P < 0.001 G2/BL: P = 0.07 G1/G2: P < 0.01 Harms: NR Modifiers: NR
| Concomitant therapies: NR N at enrollment: G1: 20 G2: 19 N at follow-up: G1: 20 G2: 19

## 2006

Cohen et al., 2006

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Cohen et al., 2006 Country: US Practice setting: Community Intervention setting: Home and school Enrollment period: 1995 to 2000 Funding: Valley Mountain Regional Center (Stockton, CA) and the child’s Special Education Local Planning Area residence Author industry relationship disclosures: NR Design: Prospective cohort | Intervention: 35–40 hours/week of Early Intensive Behavioral treatment (EIBT) based on Lovaas’ UCLA treatment model for 47 weeks/year over 3 years Intervention protocol consisted of in-home 1:1 instruction, peer play training and regular education classroom inclusion At one year into EIBT, the distribution of hours were:; - Home instruction for 26–31 hours; - Peer play for 3–5 hours; - Pre-school for 6–9 hours; Comparison group: children meeting criteria for EIBT and whose parents chose other services; controls received services from local public schools. Assessments: ADI by certified examiner at baseline; independent licensed psychologist administered standardized behavior observation, parent interview, and developmental tests, including the BSID-R, Merrill-Palmer Scale of Mental Tests, RDLS, and VABS at baseline and annual follow-up Groups: G1: EIBT G2: comparison group Provider: Staff and parents Measure of treatment fidelity reported: NR Co-interventions held stable during treatment: NR | Inclusion criteria:; - Primary diagnosis of autistic disorder/PDD-NOS based on an evaluation by an independent licensed psychologist and confirmed by ADI-R; - Pre-treatment IQ > 35 on the BSID-R; - Age 18–42 months at diagnosis and under 48 months at treatment onset; - No severe medical limitation or illness including motor or sensory deficits that would preclude a child from participating in 30 hours per week of treatment; - Residence within 60 km of the treatment agency; - No more than 400 hours of behavioral intervention prior to intake; - Parents agreed to participate actively in parent training and generalization and to have an adult present during home intervention hours; Exclusion criteria:; - See inclusion criteria; Age, years ± SD: G1: 30.2 ± 5.8 G2: 33.2 ± 3.7 Mental age: See baseline measures Gender, n (%): Male: G1: 18 (85.7) G2: 17 (81) Female: G1: 3 (14.3) G2: 4 (19) Race/ethnicity: NR | Educational/cognitive/academic/attainment: IQ, mean ± SD: G1: 61.6 ± 16.4 G2: 59.4 ± 14.7 Merrill-Palmer Scale of Mental Tests score, mean ± SD: G1: 82.4 ± 17.3 G2: 73.4 ± 11.9 Communication/language: RDLS score, mean ± SD: Comprehension: G1: 51.7 ± 15.2 G2: 52.7 ± 15.1 Expressive language: G1: 52.9 ± 14.5 G2: 52.8 ± 14.4 VABS communication score, mean ± SD: G1: 69.4 ± 11.8 G2: 65.0 ± 6.8 Adaptive behavior: VABS score, mean ± SD: Composite: G1: 69.8 ± 8.1 G2: 70.6 ± 9.6 Daily living skills: G1: 73.2 ± 9.2 G2: 72.7 ± 12.5 Social skills: VABS socialization score, mean ± SD: G1: 70.3 ± 10.9 G2: 75.1 ± 13.0 | Educational/cognitive/academic attainment: IQ, year 3, mean: G1: 87 G2: 73 (n=19) G1/G2: P < 0.05 Children in the average range, n: G1: 12 G2: 7 G1/G2: P = NS Regular education classroom placement, year 3, n: G1: 17/21^*^ G2: 1/21 G1/G2: P = 0.001 Merrill-Palmer Scale of Mental Tests score, mean change: G1: 13 G2: 13 (n=16) G1/G2: P = NS Communication/language: RDLS language comprehension score, mean: G1: 72 G2: 62 (n=19) G1/G2: P = 0.06 Children in the average range, n: G1: 8 G2: 4 G1/G2: P = NS RDLS expressive language score, mean: G1: 78 (n=20) G2: 66 (n=19) G1/G2: P = 0.13 Children in the average range, n: G1: 9 G2: 6 G1/G2: P = NS
| Concomitant therapies: NR N at enrollment: G1: 21 G2: 21 N at follow-up: G1: 21 G2: 21 | SES: Maternal education, years ± SD: G1: 15.3 ± 2.9 G2: 13.1 ± 1.6 G1/G2: P < 0.05 Paternal education, years ± SD: G1: 15.8 ± 2.9 G2: 11.8 ± 2.3 G1/G2: P < 0.05 Household income: NR Two parent household, n (%): G1: 21 (100) G2: 14 (67) G1/G2: P < 0.05 Diagnostic approach: Referral Diagnostic tool/method: DSM-IV, ADI-R Diagnostic category, n (%): Autism: G1: 20 (95.2) G2: 15 (71.4) PDD-NOS: G1: 1 (4.8) G2: 6 (28.6) Aspergers: G1: NR G2: NR G1/G2: P < 0.05 Other characteristics: NR | | VABS communication score, mean ± SD: G1: NR^***^ G2: NR^***^ G1/G2: P < 0.05 Adaptive Behavior: VABS composite score, mean change: G1: 9 (n=20) G2: −4 (n=20) G1/G2: P < 0.01 Children in the average range, n: G1: 8 G2: 3 G1/G2: P = 0.10 VABS daily living skills score, mean: G1: NR^***^ G2: NR^***^ G1/G2: P < 0.05 Social skills: VABS socialization score, mean: G1: NR^***^ G2: NR^***^ G1/G2: P < 0.10 Harms: NR Modifiers: NR

Comments:

* The difference between groups for change in IQ score was no longer significant when father’s education was added as a covariate.

** 6 children were fully included without assistance, 4 were fading the shadow, and 7 required full shadows.

*** data only illustrated graphically.

Eldevik et al., 2006

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Eldevik et al., 2006 Country: Norway Practice setting: Academic Intervention setting: School Enrollment period: 1993 to 2001 Funding Agency: Akershus University Hospital; Helge Morset Fond, Norway; NFBU; Norwegian Red Cross & Stiftelsen SOR Author industry relationship disclosures: NR Design: Retrospective cohort | Intervention: Low intensity behavioral intervention vs. eclectic treatment Low intensity behavioral intervention was approximately 12 hours/week ABA based on UCLA model behavior therapy for a period of 2 years Eclectic treatment includes at least 2 of the following intervention types: alternative communication, ABA, total communication sensory motor therapies, programs based on the principles of TEACCH Duration of treatment, months ± SD (range): G1: 20.3 ± 5.3 (13–28) G2: 21.4 ± 6.4 (14–30) Assessments: ADI-R at baseline; BSID-II, WPPSI-R, WISC-R, RDLS, PEP-R, VABS, MPS, pathology checklist (1=symptom present, 0=absent) conducted at intake and after 2 years of treatment Supervisors completed retrospective question-naire about the type of treatment or special education each child’s program was based on 6 months to 3 years after the rest of the post-treatment assessments Groups: G1: low-intensity behavioral therapy G2: eclectic treatment Provider:; - Teachers, parents, individual aides, case supervisors; - Licensed psychologists | Inclusion criteria:; - Diagnosis of autism and mental retardation by ICD-10 from a licensed psychologist and/or a medical doctor; - Age < 6 years at start of treatment; - Treatment record indicating 10–20 hours/week of one-to-one treatment; - Assessments of intellectual functioning, adaptive behavior and language conducted pretreatment and after two years of treatment; Exclusion criteria:; - Medical conditions that could interfere with treatment, such as uncontrollable epilepsy or major motor delays; Age, months ± SD (range): G1: 53 ± 9.5 (36–68) G2: 49 ± 16.9 (21–69) Mental age: IQ score, mean: 41 Gender, n: Male: G1: 10 G2: 14 Female: G1: 3 G2: 1 Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In Study Diagnostic tool/method: ADI-R, clinical judgment by independent professional Diagnostic category, n: Autism: 26 PDD-NOS: NR Aspergers: NR | Educational/cognitive/academic attainment: Intellectual functioning (BSID-II, WISC-R, WPPSI-R, SB) ratio score, mean ± SD: G1: 41.0 ± 15.2 G2: 47.2 ± 14.7 Merrill Palmer non-verbal intelligence score, mean ± SD: G1: 68.2 ± 28.3 (n=8) G2: 72.0 ± 22.1 Language comprehension (RDLS or PEP-R) ratio score, mean ± SD: G1: 37.3 ± 11.7 G2: 44.0 ± 17.7 Expressive language (RDLS or PEP-R) ratio score, mean ± SD: G1: 33.8 ±10.6 G2: 41.6 ±15.4 Adaptive behavior: VABS score, mean ± SD: Composite: G1: 52.5 ± 3.9 G2: 52.5 ± 9.6 Communication: G1: 54.1 ± 7.0 G2: 54.7 ± 10.0 Daily living skills: G1: 56.7 ± 6.0 G2: 54.5 ± 15.2 Socialization: G1: 53.7 ± 3.7 G2: 59.3 ± 7.8 Problem behavior: Pathology checklist score, mean ± SD: No words: G1: 0.4 ± 0.5 G2: 0.5 ± 0.5 | Educational/cognitive/academic attainment: Intellectual functioning (BSID-II, WISC-R, WPPSI-R, SB) ratio score, mean ± SD: G1: 49.2 ± 16.6 G2: 44.3 ± 18.9 G1/G2: P < 0.001 Merrill Palmer non-verbal intelligence score, mean ± SD: G1: 76.9 ± 27.2 (n=8) G2: 61.5 ± 24.5 G1/G2: P = NS Language comprehension (RDLS or PEP-R) ratio score, mean ± SD: G1: 44.3 ± 17.8 G2: 33.2 ± 24.7 G1/G2: P < 0.05 Expressive language (RDLS or PEP-R) ratio score, mean ± SD: G1: 44.8 ± 19.2 G2: 34.1 ± 26.2 G1/G2: P < 0.05 Adaptive behavior: VABS score, mean ± SD: Composite: G1: 52.4 ± 9.2 G2: 47.7 ± 10.2 G1/G2: P = NS Communication: G1: 58.8 ± 12.8 G2: 50.2 ± 9.4 G1/G2: P < 0.01 Daily living skills: G1: 53.7 ± 9.9 G2: 47.2 ± 14.6 G1/G2: P = NS
| Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 13 G2: 15 N at follow-up: G1: 13 G2: 13 | Other characteristics: Therapists per child, range: G1: 2–4 G2: 2–4 | Affectionate: G1: 0.9 ± 0.3 G2: 0.7 ± 0.5 Toy play: G1: 0.8 ± 0.4 G2: 0.9 ± 0.4 Peer play: G1: 1.0 ± 0.0 G2: 0.9 ± 0.4 Stereotypies: G1: 1.0 ± 0.0 G2: 0.9 ± 0.3 Temper tantrums: G1: 0.4 ± 0.5 G2: 0.5 ± 0.5 Toilet trained: G1: 0.8 ± 0.4 G2: 0.6 ± 0.5 Sum pathology: G1: 5.3 ± 1.1 G2: 4.9 ± 1.6 | Socialization: G1: 56.2 ± 5.2 G2: 57.9 ± 12.1 G1/G2: P = NS Problem behavior: Pathology checklist score, mean change ± SD: No words: G1: −0.3 ± 0.5 G2: −0.1 ± 0.3 G1/G2: P = NS Affectionate: G1: −0.7 ± 0.4 G2: −0.2 ± 0.4 G1/G2: P < 0.001 Toy play: G1: −0.6 ± 0.5 G2: −0.3 ± 0.4 G1/G2: P < 0.01 Peer play: G1: −0.4 ± 0.5 G2: 0.0 ± 0.0 G1/G2: P < 0.01 Stereotypies: G1: −0.1 ± 0.3 G2: 0.0 ± 0.0 G1/G2: P = NS Temper tantrums : G1: −0.3 ± 0.5 G2: 0.0 ± 0.5 G1/G2: P = NS Toilet trained: G1: −0.6 ± 0.5 G2: −0.2 ± 0.4 G1/G2: P < 0.05 Sum pathology: G1: −3.1 ± 1.2 G2: −0.7 ± 1.3 G1/G2: P < 0.001 Harms: NR Modifiers: Age associated with intellectual functioning in the eclectic treatment group

Gevers et al., 2006

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Gevers et al., 2006 Country: Netherlands Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: Prospective case series | Intervention: Theory of Mind (TOM) to the child, with an average duration of 7 months Social-cognition training to the parents (5 monthly sessions) Assessments: Multidisciplinary assessment by a specialized team and parent report TOM Test and VABS assessed prior to training and within 4 weeks after completion of treatment Groups: G1: TOM and social cognition training Provider: Special team Measure of treatment fidelity reported: NR Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 18 N at follow-up: G1: 18 | Inclusion criteria:; - Met DSM-IV criteria for PDD-NOS; - WISC-R Verbal IQ > 85 with average intelligence; Exclusion criteria:; - See inclusion criteria; Age years (range): 8–11 Mental age: WISC-R Verbal IQ, mean ± SD: 97.1 ± 14.9 WISC-R Verbal IQ > 85, n (%): 18 (100) Gender, n (%): Male: 13 (72.2) Female: 5 (27.8) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In Study Diagnostic tool/method: DSM-IV for PDD-NOS Diagnostic category, n (%): Autism: NR PDD-NOS: 18 (100) Aspergers: NR Other characteristics: NR | Social skills: TOM Test score, mean ± SD: Total: G1: 52.8 ± 7.8 Perception/imitiation: G1: 6.6 ± 1.5 Emotion recognition: G1: 5.0 ± 0.0 Pretense: G1: 4.1 ± 1.3 Distinction physicalmental: G1: 2.8 ± 0.6 TOM 1: G1: 18.4 ± 2.4 First order belief: G1: 24.3 ± 4.9 False belief: G1: 2.6 ± 0.6 TOM 2: G1: 27.0 ± 4.8 Second order belief: G1: 0.6 ± 0.5 Irony/humor: G1: 6.9 ± 2.2 TOM 3: G1: 7.7 ± 2.4 Adaptive behavior: VABS socialization subdomain score, developmental quotient, mean ± SD: Interpersonal relationships: G1: 0.36 ± 0.09 Play/leisure: G1: 0.39 ± 0.10 Social skills: G1: 0.51 ± 0.13 | Social Skills: TOM Test score, mean ± SD: Total: G1: 62.7 ± 5.2 G1/BL: P = 0.000 Perception/imitiation: G1: 8.2 ± 1.2 G1/BL: P = 0.000 Emotion recognition: G1: 4.9 ± 0.2 G1/BL: P = NS Pretense: G1: 4.8 ± 0.5 G1/BL: P = 0.039 Distinction physical-mental: G1: 2.9 ± 0.2 G1/BL: P = NS TOM 1: G1: 20.9 ± 1.2 G1/BL: P = 0.000 First order belief: G1: 29.6 ± 2.6 G1/BL: P = 0.001 False belief: G1: 2.7 ± 0.6 G1/BL: P = NS TOM 2: G1: 32.3 ± 3.0 G1/BL: P = 0.001 Second order belief: G1: 0.8 ± 0.4 G1/BL: P = NS Irony/humor: G1: 8.7 ± 1.6 G1/BL: P = 0.002 TOM 3: G1: 9.5 ± 1.9 G1/BL: P = 0.001
| | | | Adaptive Behavior: VABS socialization subdomain score, developmental quotient, mean ± SD: Interpersonal relationships: G1: 0.42 ± 0.14 G1/BL: P = 0.021 Play/leisure: G1: 0.47 ± 0.10 G1/BL: P = 0.013 Social skills: G1: 0.61 ± 0.15 G1/BL: P = 0.000 Harms: NR Modifiers: NR

Heimann et al., 2006

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Heimann et al., 2006 Country: Norway Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: Meltzer Foundation, University of Bergen Author industry relationship disclosures: NR Design: RCT | Intervention: Imitation interaction vs. contingent, non-imitative interaction Assessments: PEP-R subscales for imitation, perception, cognitive performance and cognitive verbal administered 4–8 weeks before treatment and again after treatment Social interest composite score created from coding scheme of Nadel et al. 2000 adapted to measure social behaviors in still-face and free play phases Duration: Four 3-minute phases of still face procedure, intervention, still-face, and free play initially conducted then repeated after 30–60 minute break Frequency: four-phase procedure conducted twice in one session Groups: G1: imitation interaction G2: contingent interaction Provider: NR Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NA Concomitant therapies, n: Imitation training: G1: 0 G2: 2 N at enrollment: G1: 10 G2: 10 N at follow-up: G1: 10 G2: 10 | Inclusion criteria:; - Non-verbal children with autism spectrum disorder by ICD-10 criteria; Exclusion criteria:; - See inclusion criteria; Age, years (range): 6.42 (4.33, 12.75) Age, months ± SD: G1: 87.0 ± 32.5 G2: 67.4 ± 10.1 Mental age, years ± SD (range): 2.08 ± 1.0 (1–4.42) Developmental age, months ± SD: PEP-R: G1: 23.2 ± 10.4 G2: 27.5 ± 13.5 Perceptual age: G1: 27.8 ± 14.0 G2: 35.5 ± 20.5 Cognitive non-verbal: G1: 22.1 ± 9.3 G2: 24.6 ± 13.5 Cognitive verbal: G1: 23.9 ± 9.6 G2: 23.7 ± 11.1 Imitation age: G1: 19.1 ± 12.4 G2: 26.3 ± 13.5 Language age (PEP), mean ± SD: G1: 23.0 ± 8.9 G2: 24.2 ± 12.0 Gender, n (%): Male: 19 (95) Female: 1 (5) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral | Social skills: Proportion of time displaying social interest, still-face phases, %: G1: NR^*^ G2: NR^*^ G1/G2: P = NS Proportion of time displaying social interest, free play phases, %: G1: NR^*^ G2: NR^*^ G1/G2: P = NS PEP-R imitation subscale score, mean ± SD: G1: 19.1 ± 12.4 G2: 26.3 ± 13.6 G1/G2: P = NS | Social skills: Proportion of time displaying social interest, still-face phases, % ± SD: G1: 35.23 ± 31.01 G2: 12.90 ± 14.59 G1/BL: P < 0.05 G2/BL: P = NS G1/G2: P < 0.05 Proportion of time displaying social interest, free play phases, % ± SD: G1: 33.7 ± 14.6 G2: 21.5 ± 11.8 G1/BL: P < 0.05 G2/BL: P = NS G1/G2: P < 0.05 PEP-R imitation subscale score, mean change ± SD: G1: 6.5 ± 9.6 G2: −0.6 ± 2.8 G1/BL: P < 0.05 G2/BL: P = NS G1/G2: P < 0.01 Harms: NR Modifiers: NR
| | Diagnostic tool/method: NR Diagnostic category, n (%): Autism: 20 (100) Other characteristics: NR

Comments:

* Data only illustrated graphically.

Henry et al., 2006

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Henry et al., 2006 Country: US Practice setting: Academic Intervention setting: Clinic (neuro-developmental) Enrollment period: July 2001 to January 2004 Funding: NR Author industry relationship disclosures: None Design: Retrospective case series | Intervention: Subjects treated with an SSRI:^*^ SSRI, n (%): Sertraline: 31 (34.8) Citalopram: 25 (28.1) Paroxetine: 15 (16.9) Fluvoxamine: 10 (11.2) Fluoxetine: 6 (6.7) Escitalopram: 2 (2.2) Mean dose, mg (SE): Sertraline: 46.7 (47.54) Citalopram:10.42 (6.77) Paroxetine: 10.67 (4.95) Fluvoxamine: 40.28 (33.53) Fluoxetine: 18.33 (14.50) Escitalopram:11.25 (12.37) Treatment duration was 7.8 ± 7.6 months Assessments: Diagnosis using DSM-IV, parental interview, child exam, record review by trained child and adolescent psychiatrists SCI-I and CGI-S scales completed by reviewers Groups: G1: PDD subjects treated with SSRIs Co-interventions held stable during treatment: NR Frequency of contact during study: NA Concomitant therapies, n : Alpha-2 agonists: 22 Psychostimulants: 20 Atypical antipsychotics: 15 Mood stabilizers: 3 Atomoxetine: 6 Gabapentin: 3 Bupropion: 2 Buspirone: 2 Lorazepam: 1 Phenytoin: 1 Levothyroxine: 1 | Inclusion criteria:; - Age 18 or younger; - DSM-IV diagnosis of autism, Asperger disorder or PDD-NOS; - Subjects treated with an SSRI; Exclusion criteria:; - See inclusion criteria; Age, years ± SD (range): 8.6 ± 3.4 (3–18) Mental age: NR Gender, n (%): Male: 80 (90) Female: 9 (10) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: DSM-IV-chart review Diagnostic category, n (%): Autism: 50 (56) PDD-NOS: 33 (37) Aspergers: 6 (7) Other characteristics: Comorbid Diagnoses, n: ADHD-NOS: 5 Mental retardation: 4 Anxiety disorder NOS: 3 Mood disorder NOS: 3 Oppositional-defiant disorder: 3 Adjustment disorder: 1 PTSD: 1 Cleft lip: 1 Central hypomyleination: 1 Complex II mitochondrial disorder: 1 Seizure disorder: 1 Hypotonia/hypermobility: 1 Lead poisoning: 1 | Overall ratings: CGI-S score, mean ± SD: G1: 4.55 ± 0.71 | Overall ratings: CGI-I score, mean ± SD: G1: 2.93 ± 1.11 Trial outcome, n (%): Much or very much improved: 40/89 (44.9) Worsened: 9/89 (10.1) Failed trial due to AEs or lack of efficacy: 28/89 (31.5) Lost to outside follow-up: 16/89 (18) Drop out, reason unknown: 3/89 (3.4) Response rate by SSRI, %: Sertraline: 55 Citalopram: 44 Paroxetine: 53 Fluvoxamine: 30 Fluoxetine: 0 Escitalopram: 50 (P = 0.19) Response rate by indication, %: Anxiety: 48 Perseverations: 44 Aggression: 45 Depressed mood: 60 (P = 0.86) Response rate by diagnosis, %: Autism: 46 Asperger disorder: 33 PDD-NOS: 46 (P = 0.84) Response rate by family history, % (P-value for correlation with positive outcome): PDDs: 72 (P = 0.011)^**^
| N at enrollment: G1: 89 N at follow-up: G1: 89 | Indications, n: Anxiety: 61 Perseverations: 59 Aggression: 31 Depressed mood: 5 Family history, n: PDDs: 18 Bipolar disorder: 12 Depression: 36 Mood disorder NOS: 2 Obsessive-compulsive Disorder: 10 Panic disorder: 5 Anxiety NOS: 14 Posttraumatic stress disorder: 1 Phobia: 1 Tic disorder: 2 Schizophrenia: 6 Psychosis NOS: 2 Mental retardation: 3 Learning disabililty: 7 Attention-deficit/hyperactivity disorder: 18 Substance abuse: 12 | | Bipolar disorder: 33 (P = 0.364) Depression: 44 (P = 0.874) Mood disorder NOS: 0 (P = 0.192) Obsessive-compulsive disorder: 30 (P = 0.297) Panic disorder: 60 (P = 0.501) Anxiety NOS: 43 (P = 0.831) PSD: 0 (P = 0.359) Phobia: 100 (P = 0.271) Tic disorder: 100 (P = 0.117) Schizophrenia: 67 (P = 0.28) Psychosis NOS: 100 (P = 0.117) Mental retardation: 100 (P = 0.108) Learning disabililty: 57 (P = 0.517) Attention-deficit/hyperactivity disorder: 44 (P = 0.923) Substance abuse: 25 (P = 0.126)
| | | | Harms: Activation side effects, n (%): Total: 48 (53.9) Agitation: 31 (34.8) Aggression: 9 (10.1) Increased impulsivity: 9 (10.1) Increased distractibility: 6 (6.7) Increased hyperactivity: 9 (10.1) Insomnia: 11 (12.4) Euphoria: 1 (1.1) Other side effects, n (%): Diarrhea: 4 (4.5) Decreased appetite: 3 (3.4) Constipation: 3 (3.4) Headaches: 1 (1.1) Tics: 1 (1.1) Stomach upset: 1 (1.1) Increased stereotypy: 1 (1.1) Increased perseverations: 1 (1.1 ) Increased anxiety: 1 (1.1 ) Psychosis: 1 (1.1) Yawning: 1 (1.1) Pica: 1 (1.1) Weight gain: 1 (1.1) Priapism: 1 (1.1)
| | | | Modifiers: 75% of subjects with family history of bipolar disorder have activation side effects (P = 0.13; RR = 2.50, 95%CI: 0.73–8.62) No association between age and activation side effects observed

Comments:

* For subjects treated with more than one SSRI during this period, only the first trial was analyzed in order to have all the SSRI trials reference separate subjects, keeping the trials independent.

** RR = 3.12, 95% CI: 1.216–8.005

Jung et al., 2006

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Jung et al., 2006 Country: South Korea Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: Korea Research Foundation Grant Author industry relationship disclosures: NR Design: Prospective case series | Intervention: SIT (based on the virtual reality tangible interaction system, with three components: coordination ability measurement, social skill training, and sensory integration); 10 sessions, length NR Assessments: VCAA (a measuring program for visuomotor coordination ability, levels controlled by the therapist, breaking virtual balloons with a real stick, reaction accuracy, movement of the stick, and average reaction time), SST (social skills training) reaction time, measured at each of 10 sessions Groups: G1: SIT intervention G2: healthy controls Provider: Therapist Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 12 G2: 20 N at follow-up: G1: 11 G2: 20 | Inclusion criteria: G1:; - Ages 5–6 years; - Met DSM-IV criteria for autism; - Recruited from out-patient unit at Children’s Hospital in Seoul; G2:; - Unrelated healthy children; - Recruited from a kindergarten belonging to a university in Seoul; Exclusion criteria:; - See inclusion criteria; Age, range (years): G1: 6 G2: 5–6 Mental age, mean IQ: G1: 64 G2: NR Gender, n (%): Male: G1: 10 (83.3) G2: NR Female: G1: 2 (16.6) G2: NR Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: DSM-IV Diagnostic category, n (%): Autism: G1: 12 (100) PDD-NOS: G1: 0 Aspergers: G1: 0 | Sensory: VCAA reaction time, mean: G1: NR^*^ VCAA reaction accuracy, mean: G1: NR^*^ VCAA stick movement, mean: G1: NR^*^ Social Skills: SST reaction time, stopping balloon, mean: G1: NR^*^ SST reaction time, moving balloon, mean: G1: NR^*^ SST reaction time, reading mind, mean: G1: NR | Sensory: VCAA reaction time, mean: G1: NR^*^ G2: NR^*^ G1/BL: P = NS G1/G2: P < 0.01 (healthy children had lower reaction times) VCAA reaction accuracy, mean: G1: NR^*^ G2: NR^*^ G1/BL: P = NS G1/G2: P = NS VCAA average reaction accuracy by sound stimulus, range: G1: 51.9–60.2 VCAA stick movement, mean: G1: NR^*^ G2: NR^*^ G1/BL: P = NS G1/G2: P < 0.01 (healthy children moved the stick more) Social Skills: SST reaction time, stopping balloon, mean ± SD: G1: 21.1 ± 10.9 G2: 17.6 ± 3.1 G1/BL: P < 0.05 (reaction time decreased) G1/G2: P = NS SST reaction time, moving balloon, mean ± SD: G1: 15.8 ± 5.1 G2: 13.8 ± 3.1 G1/BL: P = 0.08 (reaction time decreased) G1/G2: P = NS
| | Other characteristics: SMS index, mean: G1: 73 G2: NR | | SST reaction time, reading mind, mean ± SD: G1: 19.3 ± 9.7 G2: 17.3 ± 4.8 G1/BL: P = NS G1/G2: P = NS Harms: NR Modifiers: Boredom; authors report increased preference for unrepeated stimuli such as running as sessions progressed

Comments:

* Data only illustrated graphically

Legoff and Sherman, 2006

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Legoff and Sherman, 2006 Country: US Practice setting: Private multi-disciplinary autism disorders clinic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: None Design: Retrospective cohort | Intervention: LEGO intervention vs. comparable (in form and intensity) individual and group therapy on a weekly basis without LEGO materials LEGO-based interactive play groups met on a weekly basis for 90 minutes and engaged in collaborative LEGO building activities and other projects Groups: G1: LEGO intervention G2: control group, Ga: autistic disorder Gb: Asperger/PDD-NOS Provider: Therapist Measure of treatment fidelity reported: NR Co-interventions held stable during treatment: NR Concomitant therapies, hrs/week, mean ± SD: Individual therapy: G1: 1.18 ± 0.43 G2: 1.30 ± 0.75 G1/G2: P = NS Group therapy: G1: 1.59 ± 0.35 G2: 1.61 ± 0.39 G1/G2: P = NS Family therapy: G1: 0.82 ± 0.66 G2: 1.05 ± 0.67 G1/G2: P = NS Therapeutic aide: G1: 11.93 ± 13.40 G2: 12.07 ± 15.13 G1/G2: P = NS Speech-language therapy: G1: 1.29 ± 0.41 G2: 1.35 ± 0.54 G1/G2: P = NS | Inclusion criteria: G1:; - Participated in both individual and group sessions continuously for at least 3 years; - Initial and follow-up assessment data were available; G2:; - Had two complete triannual assessments; - Matched the LEGO therapy subjects on subject and treatment variables; Exclusion criteria:; - Participants who started on a new psychiatric medication or changed medications (other than minor changes in dosage) during the 3 year treatment interval; Age, years ± SD: G1: 9.3 ± 1.6 G2: 10.1 ± 1.4 Mental age: See educational/cognitive/academic attainment Gender, n (%): Male: G1: 49 (81.7) G2: 47 (82.5) Female: G1: 11 (18.3) G2: 10 (17.5) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral | Social skills: VABS socialization score, mean ± SD: G1: 62.27 ± 13.43 G2: 59.95 ± 16.48 GARS social interaction, mean ± SD: G1: 11.53 ± 1.75 G2: 11.00 ± 1.72 Communication/language: VIQ, mean ± SD: G1: 82.0 ± 21.6 G2: 83.3 ± 18.8 VABS communication score, mean ± SD: G1: 67.2 ± 17.4 G2: 65.4 ± 19.2 Educational/cognitive/academic attainment: PIQ, mean ± SD: G1: 90.7 ± 17.5 G2: 89.3 ± 18.7 Wechsler FSIQ, mean ± SD: G1: 84.6 ± 16.6 G2: 85.7 ± 17.9 | Social skills: VABS socialization score, mean change ± SD: G1: 20.68 ± 10.32 G1a: 21.45 ± 10.05 G1b: 19.91 ± 10.30 G2: 10.77 ± 10.97 G2a: 11.96 ± 11.08 G2b: 9.58 ± 10.88 ANOVA: time (P < 0.001), treatment P < 0.01), interaction (G1/BL > G2/BL; P < 0.05) GARS social interaction score, mean change ± SD: G1: −3.60 ± 1.38 G1a: −3.82 ± 1.56 G1b: −3.43 ± 1.26 G2: −2.30 ± 1.45 G2a: −2.29 ± 1.42 G2b: −2.32 ± 1.55 ANOVA: time (P < 0.001), treatment P < 0.001), interaction (G1/BL > G2/BL; P < 0.01) Communication/language: VIQ, mean ± SD: G1: 86.3 ± 16.9 G2: 79.9 ± 19.0 VABS communication score, mean ± SD: G1: 75.0 ± 11.4 G2: 70.5 ± 16.9 Educational/cognitive/academic attainment: Wechsler FSIQ, mean ± SD: G1: 90.6 ± 15.8 G2: 87.1 ± 18.8
| Occupational therapy: G1: 1.24 ± 0.89 G2: 1.19 ± 0.88 G1/G2: P = NS Physical therapy: G1: 0.21 ± 1.17 G2: 0.57 ± 1.31 G1/G2: P = NS Psychiatric medications, n (%): Antipsychotics: G1: 14 (23.3) G2: 15 (26.3) G1/G2: P = NS Psychostimulants: G1: 18 (30.0) G2: 17 (29.8) G1/G2: P = NS SSRI: G1: 9 (15.0) G2: 8 (14.0) G1/G2: P = NS N at enrollment: G1: 60 G1a: 26 G1b: 34 G2: 57 G2a: 24 G2b: 33 N at follow-up: G1: 60 G1a: 26 G1b: 34 G2: 57 G2a: 24 G2b: 33 | Diagnostic tool/method: Diagnosis made on basis of comprehensive evaluations by a pediatric neuropsychologist, a child psychiatrist, a child psychologist, and a speech pathologist, all of whom were specialists in autism spectrum disorders Diagnostic category, n (%): Autism: G1: 26 (43.3) G2: 24 (42.1) Asperger’s: G1: 27 (45.0) G2: 28 (49.1) PDD-NOS: G1: 7 (11.7) G2: PDD-NOS: 5 (8.7) Other characteristics, n (%): Diagnosis, axis II: No diagnosis: G1: 41 (68.3) G2: 39 (68.4) Mild MR: G1: 16 (26.7) G2: 15 (26.3) Moderate MR: G1: 2 (3.3) G2: 3 (5.3) MR unspecified: G1: 1 (1.7) G2: 0 (0.0) | | PIQ, mean ± SD: G1: 99.3 ± 16.8 G2: 90.3 ± 18.1 Harms: NR Modifiers: No main effect or interaction effect for diagnostic group (G1a, G1b, G2a, G2b) for VABS-SD or GARS-SI In the autistic disorder group, GARS-SI outcome was significantly correlated with initial VABS-CD and VIQ scores (P < 0.05) and this relationship was found in both the LEGO and comparison groups Communication ability (measured by the VABS-CD and VIQ) was significantly correlated with outcome on the VABS-CD for both LEGO (P < 0.02) and comparison participants (P < 0.01)
| | | | Regression analyses of VABS-CD and VIQ predicting VABS-SD difference scores: G1+G2: P < 0.01 G1: P < 0.001 G2: P < 0.004 Ga: P = NS Gb: P < 0.001 G1a: P < 0.021 G1b: P < 0.019 G2a: P = NS. G2b: P < 0.004 Regression analyses of VABS-CD and VIQ predicting GARS-SI difference scores: G1+G2: P = NS G1: P = NS G2: P = NS Ga: P < 0.021 Gb: P = NS G1a: P = NS G1b: P = NS G2a: P = NS G2b: P = NS

Lopata et al., 2006

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Lopata et al., 2006 Country: US Practice setting: Academic Intervention setting: NR Enrollment period: Summer 2003 to Summer 2004 Funding: NR Author industry relationship disclosures: NR Design: Prospective case series with a randomized component (2003 participants were all assigned to G1; 2004 participants age-matched and randomized) Note: See follow-up study Lopata et al. 2008 ({#216}), years 3–4 of intervention | Intervention: Summer treatment sessions consisting of social skills alone or social skills plus behavioral treatment in groups of 4–6 children with 3 staff members Duration: 6 weeks Frequency: 5 days/week, 6 hours/day Assessments: BASC-PRS conducted immediately prior to beginning of program and at completion of treatment; BASC-TRS conducted on day 8 of program and at completion of treatment Groups: G1: social skills plus behavioral treatment G2: social skills only Provider: Undergraduate and graduate psychology and education students who received and verified training prior to program Measure of treatment fidelity reported: Yes^*^ Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 12 G2: 9 N at follow-up: G1: 12 G2: 9 | Inclusion criteria:; - Children diagnosed with Aspergers; - Completion of three-stage screening process to confirm diagnosis; Exclusion criteria:; - See inclusion criteria; Age, years ± SD (range): 10.05 ± 2.13 (6–13) Mental age: NR Gender, n (%): Male: 21 (100) Female: 0 Race/ethnicity, n (%): White: 20 (95.24) Hispanic: 1 (4.76) SES: Maternal education: NR Household income, n (%): $25,000–$35,000: 1/15 (6.7) $35,001–$50,000: 2/15 (13.3) $50,001–$70,000: 1/15 (6.7) $70,001–$95,000: 7/15 (46.7) > $95,000: 4/15 (26.7) Diagnostic approach: Confirmation of diagnosis consisted of documentation of formal Aspergers diagnosis from a licensed psychiatrist, physician, or psychologists, submission of prior testing and evaluation records, and formal assessment of cognitive and social-emotional domain Diagnostic tool/method: NR Diagnostic category, n (%): Autism: 0 (0) PDD-NOS: 0 (0) Aspergers: 21 (100) | Social skills: BASC social skills score, parent-rated, mean ± SD: G1: 40.27 ± 9.51 (n=11) G2: 40.63 ± 4.31 (n=8) BASC social skills score, teacher-rated, mean ± SD: G1: 46.58 ± 7.15 G2: 44.78 ± 5.63 Problem behavior: BASC atypicality score, parent-rated, mean ± SD: G1: 77.27 ± 17.07 (n=11) G2: 66.25 ± 14.67 (n=8) BASC atypicality score, teacher-rated, mean ± SD: G1: 52.75 ± 6.77 G2: 48.67 ± 8.19 Adaptive behavior: BASC adaptability score, parent-rated, mean ± SD: G1: 30.25 ± 10.08 (n=8) G2: 36.83 ± 5.53 (n=6) BASC adaptability score, teacher-rated, mean ± SD: G1: 46.56 ± 8.35 (n=9) G2: 43.88 ± 9.14 (n=8) | Social Skills: BASC social skills score, parent-rated, mean ± SD: G1: 43.82 ± 11.21 (n=11) G2: 41.88 ± 4.97 (n=8) G1+G2/BL: P = 0.048 BASC social skills score, teacher-rated, mean ± SD: G1: 49.33 ± 7.11 G2: 48.89 ± 5.33 G1+G2/BL: P = 0.019 Problem behavior: BASC atypicality score, parent-rated, mean ± SD: G1: 69.00 ± 15.28 (n=11); G2: 61.13 ± 12.89 (n=8) G1+G2/BL: P = 0.001 BASC atypicality score, teacher-rated, mean ± SD: G1: 54.58 ± 9.39 G2: 52.67 ± 11.43 G1+G2/BL: P = 0.031 Adaptive Behavior: BASC adaptability score, parent-rated, mean ± SD: G1: 35.63 ± 9.53 (n=8) G2: 42.83 ± 6.15 (n=6) G1+G2/BL: P = 0.009
| | Other characteristics: NR | | BASC adaptability score, teacher-rated, mean ± SD: G1: 43.00 ± 4.56 (n=9) G2: 43.00 ± 4.38 (n=8) G1+G2/BL: P = 0.151 Harms: NR Modifiers: NR

Ludlow et al., 2006

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Ludlow et al., 2006 Country: UK Practice setting: Academic Intervention setting: NR Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: Prospective case series | Intervention: Colored overlays; participants selected the best color and side (matt or gloss) for clarity over text Frequency/duration: Single session Assessments: BPVS, City University Color Vision Test (max = 16), Ishihara Color Test (max = 38) Groups: G1: Autistic children Ga: colored overlay, chosen for clarity Gb: no colored overlay Provider: NR Measure of treatment fidelity reported: NR Co-interventions held stable during treatment: Yes Concomitant therapies: NR N at enrollment: G1: 19 N at follow-up: G1: 19 | Inclusion criteria:; - Attend a school in which a formal diagnosis of autism is necessary; Exclusion criteria:; - See inclusion criteria; Age, mean/yrs (range): G1: 11.10 ± 2.23 (8.3,15.1) Mental age: NR Gender: NR Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: NR Diagnostic category, n (%): Autism: 19 (100) Other characteristics: NR | Communication/language: BPVS score, mean ± SD: G1: 64.32 ± 10.91 Sensory: City University Color Test score, mean ± SD: G1: 15.9 ± 0.33 Ishihara Color Test score, mean ± SD: G1: 36.7 ± 1.04 | Sensory: Words read per minute, mean: G1a: NR^*^ G1b: NR^*^ G1a/G1b: P < 0.004 Educational/cognitive/academic attainment: Percentage improvement reading with colored overlays, n (%): Less than 5%: G1: 4 (21) 5–10%: G1: 3 (16) 11–20%: G1: 6 (31) 21–30%: G1: 0 31–40%: G1: 4 (21) 41–50%: G1: 2 (10) Harms: NR Modifiers: The correlation between verbal IQ measured via BPVS and degree of improvement using overlay was not significant

Comments:

* Data only illustrated graphically.

Mousain-Bosc et al., 2006

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Mousain-Bosc et al., 2006 Country: France Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: Sanofi-Aventis Author industry relationship disclosures: NR Design: Prospective case series | Intervention: Mg-vitamin B6 regimen: (6 mg/kg/day Mg, 0.6 mg/kg/d vitamin B6) for an average of 8 ± 5 months (range 2–40 months) Assessments: Symptoms and symptom groups of PDD from the DSM-IV evaluated by the physician after discussion with parents and teachers Biological parameters measured at first clinic visit of child then after 2 months of treatment; subsequent evaluations depended on the frequency of visits. Children were followed over a period of about 24 months Groups: G1: Mg-B6 therapy Co-interventions held stable during treatment: Yes Frequency of contact during study: NR Concomitant therapies, n (%): G1: 0 N at enrollment: G1: 33 N at follow-up: G1: 33 | Inclusion criteria:; - Clinical symptoms of PDD as described in DSM-IV (G1); Exclusion criteria: See inclusion criteria Age, years ± SD (range): G1: 4 ± 2 (1–10) Mental age: NR Gender, n: Male: G1: 21 Female: G1: 12 Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In Study Diagnostic tool/method: DSM-IV Diagnostic category, n (%): PDD: G1: 33 (100) Other characteristics: NR | Social skills: DSM-IV visual contact score, mean ± SD: G1: 3.33 ± 0.89 DSM-IV visual contact score > 3, n: G1: 26 DSM-IV connection with equals score, mean ± SD: G1: 3.12 ± 0.74 DSM-IV connection with equals score > 3, n: G1: 28 DSM-IV delight partition score, mean ± SD: G1: 3.03 ± 0.81 DSM-IV delight partition score > 3, n: G1: 25 DSM-IV social reciprocity score, mean ± SD: G1: 3.30 ± 0.68 DSM-IV social reciprocity score > 3, n: G1: 29 DSM-IV social interactions total score, mean ± SD: G1: 12.61 ± 3.01 Communication/language: DSM-IV delayed communication score, mean ± SD: G1: 3.39 ± 0.50 DSM-IV delayed communication score > 3, n: G1: 33 DSM-IV no communication score, mean ± SD: G1: 3.09 ± 0.72 | Overall ratings: Improvement for ¾ groups of symptoms, n: G1: 20/30 Social skills: DSM-IV visual contact score, mean ± SD: G1: 1.36 ± 1.19 DSM-IV visual contact score > 3, n: G1: 6 DSM-IV connection with equals score, mean ± SD: G1: 1.51 ± 1.00 DSM-IV connection with equals score > 3, n: G1: 6 DSM-IV delight partition score, mean ± SD: G1: 1.54 ± 1.06 DSM-IV delight partition score > 3, n: G1: 6 DSM-IV social reciprocity score, mean ± SD: G1: 1.51 ± 1.06 DSM-IV social reciprocity score > 3, n: G1: 6 DSM-IV social interactions total score, mean ± SD: G1: 5.94 ± 4.10 G1/BL: P = 0.0000
| | | DSM-IV no communication score > 3, n: G1: 26 DSM-IV stereotyped language score, mean ± SD: G1: 2.85 ± 0.71 DSM-IV stereotyped language score > 3, n: G1: 24 DSM-IV social mimicking score, mean ± SD: G1: 3.27 ± 0.75 DSM-IV social mimicking score > 3, n: G1: 29 DSM-IV loss of communication total score, mean ± SD: G1: 12.61 ± 2.16 Repetitive behavior: DSM-IV stereotyped interest score, mean ± SD: G1: 3.03 ± 1.16 DSM-IV stereotyped interest score > 3, n: G1: 24 DSM-IV customs score, mean ± SD: G1: 1.88 ± 1.36 DSM-IV customs score > 3, n: G1: 12 DSM-IV motor affection score, mean ± SD: G1: 2.36 ± 1.14 DSM-IV motor affection score > 3, n: G1: 17 | DSM-IV social interactions total score, change > 5, n: G1: 23/33 Communication/language: DSM-IV delayed communication score, mean ± SD: G1: 2.00 ± 1.00 DSM-IV delayed communication score > 3, n: G1: 9 DSM-IV no communication score, mean ± SD: G1: 1.54 ± 0.87 DSM-IV no communication score > 3, n: G1: 4 DSM-IV stereo-typed language score, mean ± SD: G1: 1.54 ± 1.09 DSM-IV stereo-typed language score > 3, n: G1: 6 DSM-IV social mimicking score, mean ± SD: G1: 1.39 ± 1.05 DSM-IV social mimicking score > 3, n: G1: 5 DSM-IV loss of communication total score, mean ± SD: G1: 6.48 ± 3.77 G1/BL: P = 0.0000
| | | DSM-IV things handling score, mean ± SD: G1: 1.88 ± 1.17 DSM-IV things handling score > 3, n: G1: 10 DSM-IV stereotyped restricted behavior total score, mean ± SD: G1: 12.61 ± 2.16 Adaptive behavior: DSM-IV social interactions score, mean ± SD: G1: 3.26 ± 0.89 DSM-IV social interactions score > 3, n: G1: 28 DSM-IV language score, mean ± SD: G1: 3.39 ± 0.62 DSM-IV language score > 3, n: G1: 29 DSM-IV symbolic games score, mean ± SD: G1: 3.13 ± 0.88 DSM-IV symbolic games score > 3, n: G1: 27 DSM-IV abnormal or delayed functioning total score, mean ± SD: G1: 12.61 ± 2.16 Medical: Erc-Mg (mmol/L), mean ±SD: G1: 2.17 ± 0.4 i-Ca (mmol/L), mean ± SD: G1: 1.21 ±0.08 | DSM-IV loss of communication total score, change > 5, n: G1: 24/33 Repetitive behavior: DSM-IV stereo-typed interest score, mean ± SD: G1: 1.27 ± 0.91 DSM-IV stereotyped interest score > 3, n: G1: 3 DSM-IV customs score, mean ± SD: G1: 0.64 ± 0.82 DSM-IV customs score > 3, n: G1: 1 DSM-IV motor affection score, mean ± SD: G1: 1.00 ± 0.90 DSM-IV motor affection score > 3, n: G1: 3 DSM-IV things handling score, mean ± SD: G1: 1.03 ± 1.04 DSM-IV things handling score > 3, n: G1: 3 DSM-IV stereotyped restricted behavior total score, mean ±SD: G1: 6.48 ±3.77 G1/BL: P = 0.0000
| | | s-Mg (mmol/L), mean ± SD: G1: 0.89 ± 0.06 | DSM-IV stereotyped restricted behavior total score, change > 5, n: G1: 18/33 Adaptive behavior: DSM-IV social interactions score, mean ± SD: G1: 1.80 ± 1.22 DSM-IV social interactions score > 3, n: G1: 10 DSM-IV language score, mean ± SD: G1: 1.90 ± 1.22 DSM-IV language score > 3, n: G1: 10 DSM-IV symbolic games score, mean ± SD: G1: 1.66 ± 1.15 DSM-IV symbolic games score > 3, n: G1: 9 DSM-IV abnormal or delayed functioning total score, mean ± SD: G1: 6.48 ± 3.77 G1/BL: P = 0.0000 DSM-IV abnormal or delayed functioning total score, change > 5, n: G1: 17/33 Medical: Erc-Mg (mmol/L), mean ± SD:^**^ G1: 2.42 ± 0.41 G1/BL: P = 0.0198
| | | | Erc-Mg increased, post-treatment, n (%): G1: 11/17 (65) i-Ca (mmol/L), mean ± SD: G1: 1.20 ± 0.05 G1/BL: P = NS s-Mg (mmol/L), mean ± SD: G1: NR G1/BL: P = NS Harms: NR Modifiers: NR

Comments:

* data only illustrated graphically

** Authors report when Mg supply was stopped, Erc-Mg values returned to low levels in about 2 months

Nagaraj et al., 2006

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Nagaraj et al., 2006 Country: India Practice setting: Academic Intervention setting: Pediatric neuro-development clinic Enrollment period: January 2002 to December 2003 Funding: Postgraduate Institute of Medical Education and Research, Chandigarh Author industry relationship disclosures: NR Design: RCT, block randomization, double blind study | Intervention: Liquid suspension risperidone or placebo, 0.5 mg/day orally for two weeks then 1 mg/day for the remaining 6 months Assessments: CARS, CGAS conducted by investigator at intake and every 8 weeks for 6 months Parent questionnaire designed for study Groups: G1: risperidone G2: placebo Co-interventions held stable during treatment: Yes (psychoactive medications stopped 1 month in advance of entering trial; no other drugs administered concurrently except antiepileptics); non-medical interventions not reported Frequency of contact during study: Every 8 weeks Concomitant therapies: NR N at enrollment: G1: 19 G2: 21 N at follow-up: G1: 19 G2: 20 | Inclusion criteria:; - Age ≤12 years; - Diagnosed with autism according to DSM IV criteria; Exclusion criteria:; - Severe mental retardation; - Significant co-existing disease/illness; - Severe malnutrition (weight for age < 60% of NCHS median); Age, months ± SD: G1: 57.95 ± 20.84 G2: 63.0 ± 20.12 Mental age: NR Gender, n (%): Male: G1: 16 (84.2) G2: 18 (90) Female: G1: 3 (15.8) G2: 2 (10) Race/ethnicity: NR SES: Maternal education: NR Socioeconomic class, n (%): Very high: G1: 3 (15.8) G2: 6 (30) Upper middle: G1: 10 (52.6) G2: 5 (25) Middle: G1: 5 (26.3) G2: 8 (40) Lower middle: G1: 1 (5.3) G2: 1 (5) Diagnostic approach: NR Diagnostic tool/method: Clinical interview, DSM-IV | Overall Ratings: CARS score, median (range): G1: 39.5 (32.5–46) G2: 38.5 (31.5–43) CGAS score, mean ± SD: G1: 29.79 ± 7.27 G2: 32.65 ± 7.95 IQ, n (%): Borderline IQ: G1: 9 (47.4) G2: 8 (40) Mild retardation: G1: 6 (31.6) G2: 5 (25) Moderate retardation: G1: 4 (21.1) G2: 7 (35) VABS social maturity score, mean ± SD: G1: 61.92 ± 16.16 G2: 60.64 ± 19.31 Communication/ language, n (%): Simple sentences: G1: 3 (16) G2: 2 (10) Few meaningful words: G1: 5 (26.3) G2: 5 (25) Imitate speech sounds only: G1: 7 (36.8) G2: 7 (35) Nonverbal communication: G1: 2 (10.5) G2: 5 (25) No communication: G1: 2 (10.5) G2: 1 (5) Medical: Weight, mean kg ± SD: G1: 16.17 ± 3.38 G2: 18.25 ± 5.6 Previous medication, n (%): None: G1: 15 (79) G2: 16 (80) | Overall Ratings: CARS score, median (range): G1: 32.0 (24.5–40.5) G2: 37.5 (30–42.5) G1/G2: P < 0.001 CARS score ≥ 20% improvement from baseline: G1: 12/19 G2: 0/20 CGAS score, mean ± SD: G1: 40.94 ± 7.83 G2: 35.2 ± 9.38 G1/G2: P = 0.035 CGAS score ≥ 20% improvement from baseline: G1: 17/19 G2: 2/20 Parent impresssions, global, n: Considerably improved: G1: 9/19 G2: 0/20 Improved to some extent: G1: 9/19 G2: 6/20 No change: G1: 0/19 G2: 9/20 Worsened: G1: 1/19 G2: 4/20 G1/G2: P = NS Social skills: Parent impresssions, social responsiveness, n: Significantly improved: G1: 7/19 G2: NR G1/G2: P = 0.014
| | Diagnostic category, n (%): Autism: 39 (100) Other characteristics, n (%): Lack of eye contact, gestures, other non-verbal communication: G1: 16 (84.2) G2: 19 (95) Impaired peer relation-ships, reciprocity, sharing emotions: G1: 19 (100) G2: 19 (95) Total lack of spoken language: G1: 12 (63.2) G2: 16 (80) Impaired general linguistic ability, comprehension: G1: 19 (100) G2: 20 (100) Impaired imaginative play: G1: 12 (63.2) G2: 15 (75) Restricted pattern of interests: G1: 14 (73.7) G2: 12 (60) Inflexible adherence to routine, stubbornness: G1: 10 (52.6) G2: 7 (35) Motor and verbal stereotypies: G1: 13 (68.4) G2: 11 (55) Hyperactivity: G1: 12 (63.2) G2: 14 (70) Aggressive behavior, tantrums: G1: 9 (47.4) G2: 11 (55) Irritability: G1: 17 (89.5) G2: 19 (95) Withdrawal, inattention: G1: 10 (52.6) G2: 10 (50) Self-injurious behavior: G1: 7 (36.8) G2: 5 (25) | Antipsychotic: G1: 3 (16) G2: 1 (5) Stimulant: G1: 1 (5) G2: 3 (15) | Problem behavior: Parent impresssions, decreased hyperactivity, n: Significantly improved: G1: 7/19 G2: NR G1/G2: P = 0.002 Parent impresssions, aggression and irritability, n: Significantly improved: G1: 5/19 G2: NR G1/G2: P = 0.016 Communication/ language: Parent impresssions, nonverbal communication, n: Significantly improved: G1: 8/19 G2: NR G1/G2: P = 0.008 Adaptive behavior: Increased appetite/improved eating habits, n: G1: 17/19 G2: NR Medical: Weight, mean change kg ± SD: G1: 2.81 ± 2.04 G2: 1.71 ± 1.3 Harms: Mild Sedation: G1: 4/19 G2: NR Dyskinesias: G1: 3/19 G2: NR Drooling: G1: 1/19 G2: NR Modifiers: NR
| | Seizures: G1: 5 (26.3) G2: 3 (15) Family structure, n (%): Nuclear: G1: 13 (68.4) G2: 15 (75) Joint: G1: 6 (31.6) G2: 5 (25)

Comments:

* (orolingual=2, left lower limb=1)

Sams et al., 2006

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Sams et al., 2006 Country: US Practice setting: Special treatment center, community college, hospital Intervention setting: School Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: Prospective case series | Intervention: Occupational therapy with and without animals focused on facilitating sensory integration, language use, sensory skills and motor skills Frequency: two sessions per week, one lasting 26.3 ± 6.0 minutes, and one lasting 28.5 ± 5.3 minutes incorporating animals Children ranged between 2–12 sessions of each type over 15 weeks Assessments: Observers recorded instances of social interaction and language use on a behavioral rating form at each session Groups: G1: occupational therapy Ga: standard sessions Gb: animal sessions Provider:; - Occupational therapists; - Trained research assistants (senior undergraduate occupational therapy field study students); Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 22 N at follow-up: G1: 22 | Inclusion criteria:; - School age; - Participating in school-based program (occupational therapy services through public schools); - Primary diagnosis of autism; Exclusion criteria:; - See inclusion criteria; Age, years ± SD (range): 9.6 ± 1.7 (7–13) Mental age: NR Gender: NR Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: NR Diagnostic category, n (%): Autism: 22 (100) Cerebral palsy: 2 (9) Other characteristics: NR | NR | Social skills: Social interactions per minute, mean ± SD: G1a: 0.17 ± 0.09 G1b: 0.27 ± 0.10 G1a/G1b: P < 0.01 (ES = 1.0) Communication/ language: Uses of language per minute, mean ± SD: G1a: 0.98 ± 0.72 G1b: 1.27 ± 1.10 G1a/G1b: P < 0.05 (ES = 0.31) Harms: NR Modifiers: NR

Wetherby et al., 2006

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Wetherby et al., 2006 Country: US Practice setting: Academic Intervention setting: Home, classroom Enrollment period: NR Funding: U.S. Department of Education, Office of Special Education and Rehabilitation Services Author industry relationship disclosures: NR Design: Prospective case series | Intervention: Early Social Interaction project (ESI): routines-based intervention in natural environments; individualized curriculum; parent-implemented curriculum; recommended 2 home visits/week G1 also participated in parent-child playgroup guided by two interventionists thru the FIRST WORDS project: attended for 9 weeks during the ESI intervention year Assessments: Pre- and post-intervention measures of social communication; MSEL, VABS Groups: G1: intervention (entered study at age 2 and received ESI for 1 year) G2: control (age 3) Provider: Speech language pathologists, early childhood education specialist Measure of treatment fidelity reported: Yes Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 17 G2: 18 N at follow-up: G1: 17 G2: 18 | Inclusion criteria: G1; - CSBS behavior sample from children between ages 12–24 months and again between 25–36 months after 12 months ESI; - Provisional diagnosis of autism or systemic observation of red flags of ASD during first behavior sample; - Age ≤ 24 months; - Family agreed to participate in ESI for 12 months; - Family agreed to diagnostic evaluation of child at 36 months; G2:; - CSBS DP behavior sample from 25–36 months; - No previous intervention services before behavior sample was videotaped; - Suspicion of ASD; - Family agreed to diagnostic evaluation at 36 months; Exclusion criteria:; - See inclusion criteria; Age, months ± SD: Pre-ESI: G1: 18.19 ± 3.85 Post-ESI: G1: 30.72 ± 3.66 Upon recruitment: G2: 31.61 ± 3.45 Mental age: NR Gender, %: Male: G1: 88 G2: 78 Female: G1: 12 G2: 22 Race/ethnicity, %: Caucasian: G1: 65 G2: 61 | Communication/ language: Social signals, mean ± SD: Gaze shifts: G1: 4.18 ± 1.67 G2: NA Shared positive affect: G1: 1.88 ± 1.83 G2: NA Gaze/point follow: G1: 0.35 ± 0.61 G2: NA Rate of communicating, mean ± SD: G1: 8.71 ± 5.36 G2: NA Communicative functions, mean ± SD: Behavior regulation: G1: 3.59 ± 2.12 G2: NA Social interaction: G1: 0.65 ± 0.93 G2: NA Joint attention: G1: 0.65 ± 0.93 G2: NA Communicative means inventory, mean ± SD: Gestures: G1: 1.76 ± 1.15 G2: NA Consonants: G1: 1.0 ± 1.37 G2: NA Words: G1: 0.18 ± 0.53 G2: NA Symbolic capacity, mean ± SD: Understanding: G1: 0.82 ± 1.38 G2: NA | Communication/ language: Social signals, mean ± SD: Gaze shifts: G1: 5.18 ± 1.51 G2: 3.28 ± 1.71 G1/BL: P = 0.091 G1/G2: P = 0.001 Shared positive affect: G1: 3.41 ± 2.00 G2: 1.31 ± 1.38 G1/BL: P = 0.053 G1/G2: P = 0.005 Gaze/point follow: G1: 1.29 ± 0.85 G2: 0.61 ± 0.70 G1/BL: P = 0.004 G1/G2: P = 0.014 Rate of communicating, mean ± SD: G1: 16.18 ± 2.56 G2: 11.94 ± 5.51 G1/BL: P < 0.001 G1/G2: P = 0.007 Communicative functions, mean ± SD: Behavior regulation: G1: 5.53 ± 0.63 G2: 4.11 ± 1.81 G1/BL: P = 0.002 G1/G2: P = 0.005 Social interaction: G1: 2.29 ± 1.86 G2: 0.89 ± 1.28 G1/BL: P = 0.002 G1/G2: P = 0.015 Joint attention: G1: 2.94 ± 2.16 G2: 1.39 ± 1.54 G1/BL: P = 0.001 G1/G2: P = 0.021
| | African-American: G1: 12 G2: 17 Hispanic: G1: 24 G2: 6 Asian: G1: 0 G2: 17 SES: Parent Education, years ± SD: Mother: G1: 15.7 ± 1.93 G2: 15.53± 1.63 Father: G1: 16.35 ± 2.5 G2: 15.41 ± 2.4 Hollinghead’s index of SES, mean ± SD: G1: 53.0 ± 10.42 G2: 52.94 ± 10.33 Diagnostic approach: In Study/Referral Diagnostic tool/method: MSEL, VABS interview edition, survey form; ADOS, DSM-IV-TR Diagnostic category: See inclusion criteria Other characteristics, age 3, mean ± SD: MSEL, mean ± SD: Non-verbal DQ: G1: 81.98 ± 23.93 G2: 64.23 ± 17.74 Verbal DQ: G1: 73.55 ± 26.16 G2: 56.07 ± 24.96 VABS score, mean ± SD: Communication: G1: 77.06 ± 19.76 G2: 62.76 ± 16.91 Daily living: G1: 75.88 ± 10.51 G2: 65.88 ± 19.53 Social: G1: 77.06 ± 16.35 G2: 64.41 ± 18.99 | Inventory of actions: G1: 3.88 ± 2.0 G2: NA Actions to others: G1: 0.53 ± 0.8 G2: NA Language stage, n (%): Pre-verbal: G1: 16 (94) G2: NA Verbal Early one-word: G1: 1 (6) G2: NA Late one-word: G1: 0 G2: NA Multiword: G1: 0 G2: NA Total: G1: 1 (6) G2: NA | Communicative means inventory, mean ± SD: Gestures: G1: 3.76 ± 1.68 G2: 2.72 ± 1.53 G1/BL: P = 0.001 G1/G2: P = 0.064 Consonants: G1: 4.71 ± 2.69 G2: 3.72 ± 3.08 G1/BL: P < 0.001 G1/G2: P = 0.321 Words: G1: 6.00 ± 5.18 G2: 3.94 ± 4.40 G1/BL: P < 0.001 G1/G2: P = 0.216 Symbolic capacity, mean ± SD: Understanding: G1: 4.24 ± 3.29 G2: 2.00 ± 2.40 G1/BL: P < 0.001 G1/G2: P = 0.030 Inventory of actions: G1: 6.18 ± 2.90 G2: 5.00 ± 2.28 G1/BL: P = 0.011 G1/G2: P = 0.193 Actions to others: G1: 2.82 ± 1.70 G2: 2.56 ± 1.72 G1/BL: P < 0.001 G1/G2: P = 0.065 Language stage, n (%): Pre-verbal: G1: 4 (24) G2: 8 (44) Verbal early one-word: G1: 4 (24) G2: 5 (28) Late one-word: G1: 6 (35) G2: 2 (11) Multiword: G1: 3 (18) G2: 3 (17)
| | Motor: G1: 83.76 ± 14.32 G2: 71.88 ± 21.45 Adaptive behavior Composite: G1: 73.82 ± 14.73 G2: 64.71 ± 7.20 | | Total: G1: 13 (77) G2: 10 (56) Harms: NR Modifiers: NR

Yoder, 2006

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Yoder, 2006 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NIH and other communication disorders grant Author industry relationship disclosures: NR Design: Case series, prospective Note: Shares participants with Yoder et al. 2006a ({#516}), 2006b ({#487}) & 2009 ({#5719}) | Intervention: Identify putative child (attention following, intentional communication, motor imitation, diversity of object play) and environmental factors associated with growth of lexical density Hours of treatment/month, mean ± SD (range): 16 ± 9 (11–145) Hours of communication treatment/month, mean ± SD (range): 10 ± 5 (11–29) Assessment: MSEL, Motor Imitation Scale, Developmental Play Assessment tests at baseline Lexical density measured at baseline, 6 months and 12 months using adapted version of ESCS-abridged and unstructured free play with examiner for 15 minutes Non-project treatment questionnaire administered monthly for first 6 months and at 12 months Groups: G1: intervention Provider: NR Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 35 N at follow-up: G1: 35 | Inclusion criteria:; - Diagnosis of autistic disorder or PDD-NOS; - Age 18–60 months; - Use of fewer than 10 words during two communication samples; Exclusion criteria:; - Severe sensory or motor deficits; - English not primary language spoken at home; Age, months (range): 33.6 (21–54) Mental age, months ± SD (range): MSEL nonverbal: 18.6 ± 3.7 (11.5–26.5) MSEL verbal: 11.9 ± 2.8 (7–19) Gender, n (%): Male: 31 (89) Female: 4 (11) Race/ethnicity, n (%): White: 24 (69) African American: 8 (23) Other: 3 (8) SES: Primary parent education, mean (range): 3–4 years college (10^th^ grade to > 2 years graduate school) Household income: NR Diagnostic approach: In Study Diagnostic tool/method: ADOS Diagnostic category, n (%): Autism: 32 (91) PDD-NOS: 3 (9) Aspergers: NR Other characteristics: NR | Communication/ language: MSEL cognitive standard score, mean ± SD (range): 51 ± 5.3 (48–67) MCDI number of words child understands, mean ± SD (range): 86 ± 74 (1–277) ESCS and unstructured free play lexical density, mean ± SD (range): 0.5 ± 1.0 (0–5) ESCS attention following, mean ± SD (range): 1.6 ± 2.2 (0–8) ESCS and unstructured free play intentional communication, mean ± SD (range): 25 ± 17 (4–83) Motor Imitation Scale total raw score, mean ± SD (range): 7.8 ± 6.4 (0–32) Developmental Play Assessment diversity of object play, mean ± SD (range): 39 ± 22.5 (7–123) MSEL expressive language impairment, mean ± SD (range): 21 ± 3 (19–30) | Communication/ language: ESCS and unstructured free play lexical density, mean ± SD (range): 6 months: 3 ± 5 (0–17) 12 months: 7 ± 11 (0–50) Harms: NR Modifiers: Expressive language impairment is a significant predictor of growth in lexical density (P = 0.004) After controlling for expressive language impairment, the significant predictors of growth in lexical density are intentional communication (P = 0.009) and diversity of object play (P = 0.002), but these are significantly correlated (r = 0.36; P < 0.05) The amount of communication/ speech treatment was not related to growth rate of lexical density after controlling for expressive language impairment.
| | | | Neither the total amount of therapy nor the amount of communication/ speech/language therapy interacted with baseline attention following to predict growth in lexical density

## 2005

Beglinger et al., 2005

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Beglinger et al., 2005 Country: US Practice setting: Academic Intervention setting: Home Enrollment period: NR Funding: Washington State University Author industry relationship disclosures: NR Design: Prospective case series | Intervention: Intensive behavioral treatment based on the UCLA model for 0–44 months for children enrolled in Multisite Young Autism Project (MYAP) 40 hrs/wk of one-to-one Intervention, initially extremely individualized discrete trial training to the child, later becoming complex, group-setting focused and adapted to the child’s environment. Assessments: Participants administered core assessment tests at time of intake and annually thereafter (excluding WSQ, except in a small sub-sample); if children showed improvements in functioning, the Bayley was replaced with the WPPSI-R Groups (4 subtypes of autism based on social style): G1a: Aloof G1b: Passive G1c: Active-but-odd G1d: Typically developing Provider: A team of project director, supervisor, lead therapist, student therapists and parents Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR | Inclusion criteria:; - Diagnosis of autism by a licensed psychologist or psychiatrist, using the Autism Diagnostic Interview and DSM-IV Criteria; - chronological age of not more than 42 months at referral and not more than 8 years at the time of enrollment into this study; - acceptance into the MYAP and active participation in intensive treatment (approximately 30–40 h per week) of one to-one instruction; - no major medical limitations that would impede treatment (such as cerebral palsy or motor deficits); - ratio IQ of 30 or higher on the Bayley Scales of Infant Development: Mental Development Index; Exclusion criteria: See Inclusion criteria Age, mean/yrs ± SD (range): 5.42 ± 1.08 (3–6) Mental age: NR Gender: M, n (%): 32 (86.5) F, n (%): 5 (13.5) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral | Educational/ cognitive/ academic attainment: IQ, mean ± SD (range): 54.13 ± 12.63 (32–82) IQ scores by Scale, mean ± SD: G1a: 50.6 ± 13.4 G1b: 62.4 ± 11.9 G1c: 42.4 ± 12.7 G1d: 55.8 ± 12.1 | Educational/ cognitive/ academic attainment: IQ, mean ± SD: G1a: 54.5 ± 13.5 G1b: 76.8 ± 13.4 G1c: 80.8 ± 15.2 G1d: 93.8 ± 10.1 Change in IQ in G1a was significantly smaller than in G1c (P< 0.05) and G1d (P < 0.0001) G1a subtype has the lowest functioning children followed by G1b, G1c and G1d at the highest end. WSQ summary score by Scale, mean ± SD: G1a: 29.1 ± 14.5 G1b: 33.5 ± 10.8 G1c: 28.2 ±10.3 G1d: 33.7 ± 15.5 None of WSQ scores were correlated with either age or months in treatment. Pearson values ranged from 0.19 to −0.14. Pre Tx IQ significantly correlated with WSQ summary score for G1a & G1d (P < 0.05) and is correlated with Current IQ (P = 0.001) Harms: NR
| N at enrollment: 38 N at follow-up: 37 G1a: 14 G1b: 5 G1c: 7 G1d: 9 | Diagnostic tool/method: ADI & DSM-IV Diagnostic category, n (%): Autism : 37 (100) Other characteristics: NR | | Modifiers: G1a type was negatively correlated with all IQ measures (P = 0.001) G1d type was positively highly correlated with IQ change (P = 0.001)

Farrell et al., 2005

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Farrell et al., 2005 Country: UK Practice setting: Academic Intervention setting: School and home Enrollment period: NR Funding: LEA Author industry relationship disclosures: NR Design: Retrospective cohort Note: Full account of methodology and results from interviews can be found in Trigonaki & Farrell, 2002 | Intervention: LUFAP vs. ABA/Lovaas LUFAP: children attended mainstream school full time, SSAs employed combination of delivery styles (in particular ABA techniques and TEACCH approach), weekly meetings with parents, SSA, project teacher, and class teacher ABA/Lovaas: children received a minimum of 30 hours one-to-one support per week, mainly at home, from up to 5 therapists Assessments: Semi-structured interviews conducted by staff from Manchester University near beginning and end of study with parents, class teachers, senior LEA officers, SSAs, ABA therapists, and ABA supervisors; VABS and BSID baseline and post test For all but one participant the gap between assessments was ≥ 18 months (that one participant gap between baseline and post assessment was 7 months); the mean time between assessments for G1 was 20 months and for G2 was 26 months Groups: G1: LUFAP G2: ABA/Lovaas Provider:; - The LUFAP group was managed by project team (the Head of Pupil Services Division, the Head of SEN Assessment, a representative from educational psychology service, an SEN advisor, and a project teacher | Inclusion criteria:; - Pre-school age children; - G1 selected by EPs part of a team carrying out statutory assessment; - G2 parents lobbied for Lovaas/ABA intervention; Exclusion criteria:; - See inclusion criteria; Age, 28 months into study, months: G1: 69.4 G2: 75.6 Mental age: BSID delevopmental age, months: G1: 21.8 (n=8) G2: 15.6 (n=5) Gender, n: Male: G1: 7 G2: 6 Female: G1: 2 G2: 2 Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral by educational psychologist in Lancashire Diagnostic tool/method: NR Diagnostic category: Autism: 17 (100) Other characteristics: NR | Social skills: VABS socialization, developmental age, months: G1: 15.7 G2: 11 (n = 6) Communication/ language: VABS communication, developmental age, months: G1: 17.9 G2: 11.6 (n = 6) Adaptive behavior: VABS daily living, developmental age, months: G1: 19.7 G2: 18.1 (n = 6) Educational/cognitive/academic attainment: BSID developmental age, months: G1: 21.8 (n=8) G2: 15.6 (n=5) | Social skills: VABS socialization, developmental age, months: G1: 27.4 (n=7) G2: 21 (n=7) VABS socialization, progress made per month, mean: G1: 1.02 (n=7) G2: 0.34 (n=6) Communication/ language: VABS communication, developmental age, months: G1: 50.6 (n=7) G2: 25.3 (n=7) VABS communication, progress made per month, mean: G1: 1.57 (n=7) G2: 0.43 (n=6) Adaptive behavior: VABS daily living, developmental age, months: G1: 35.0 (n=7) G2: 34.4 (n=7) VABS daily living, progress made per month, mean: G1: 0.65 (n=7) G2: 0.5 (n=6) Educational/ cognitive/ academic attainment: BSID developmental age, months: G1: 29.8 (n=5) G2: 27.2 (n=4)
| - For the LUFAP group day-to-day implementtation: project teachers (1.5 full time staff), SSAs (one full time for each child), and half time speech and language therapist, supported by educational psychologists; - The ABA/Lovass team consisted of children’s parents, lead therapist, a team of therapists, trained ABA supervisors from the UK and ABA consultants from the USA; Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 9 G2: 8 N at follow-up: G1: 7 G2: 7 | | | BSID, progress made per month, mean: G1: 0.9 (n=4) G2: 0.56 (n=4) Harms: NR Modifiers: NR

Grey et al., 2005

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Grey et al., 2005 Country: Ireland Practice setting: Academic Intervention setting: University Classroom Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: case series | Intervention: Teacher Training in Applied Behavior Analysis using Person Focused Training (see Provider below) . Teachers identified target behavior and intervention goal for one child with autism in their classrooms. Duration: 10.2 Months Frequency: sessions with children Varied – See Baseline Measures Assessments: All of the following were Participant Completed:; - Comprehensive Function Assessment – included child’s ecological background, schedule of daily activities, social interactions, functions, cognitive ability, health issues, and life story; - Inventory of favorite things; - Communication Assessment - including receptive and expressive language ability; Groups: G1a: goal of reduction in target Behavior G1b: goal of increase in target Behavior Provider: 11 Female Special Needs Teachers with general education degrees or diplomas. All teachers underwent 90 hours of classroom instruction/supervision (45 hours – basic principles of ABA, 45 hour – application of said principles in practical settings.) Duration of training lasted 13 days over a 7 month period | Inclusion criteria:; - Autistic Disorder; Exclusion criteria: See Inclusion Criteria Age, mean/yrs (range): 8 years 2 months (2 years 10 months – 15 years) Mental age: NR Gender: M, n (%): 8 (73) F, n (%): 3 (27) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: NR Diagnostic category, n (%): Autism: 11 (100) Other characteristics: | Baseline Sessions for each child, mean ± SD (range): 11.5 ± 7.4 (3–23) Problem Behavior: Frequency of Occurrence of target behavior, mean ± SD (range): G1a: 23.5 ± 19.8 (2.9–54) G1b: 5.8 ± 4.8 (1.4–11) | Intervention Sessions mean ± SD (range): 12 ± 9.3 (3–27) Problem behavior: Frequency of Target Behavior, mean ± SD (range): G1a: 7.2 ± 9.2 (0.6–26.7) G1a: Reduction in rate of target behavior (Z = −2.521, P < 0.05) G1b: 13.6 ± 11.3 (1.7–24.3) [not able to perform statistical tests] Harms: NR Modifiers: NR
| Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1a: 8 G1b: 3 N at follow-up: G1a: 8 G1b: 3

Hollander et al., 2005

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Hollander et al., 2005 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: FDA NIH Author industry relationship disclosures: NR Design: Randomized double-blind, cross-over study | Intervention: Liquid fluoxetine or placebo 2.5 mg/day for week 1, titrated as indicated by subject’s symptoms and side effects based on weight for the next 2 weeks up to 0.8 mg/kg/day (0.3 mg/kg for week 2, 0.5 mg/kg/day for week 3, and 0.8 mg/kg/day for weeks 4–8) Mean maximum dose for fluoxetine: 10.6 ±3.65 mg (range 4.8–20), or 0.38 ± 0.97 mg/kg Mean final dose for fluoxetine: 9.9 mg ± 4.35 (range 2.4–20 mg), or 0.36 ± 0.116 mg/kg. 3 treatment phases: 8 week randomized control trial 4 week wash out period 8 week cross over study Assessments: Clinical Global Improvement Scale Adapted to Autism, Children’s Yale-Brown Obsessive –Compulsion Scale, Global Autism Composite Improvement, Overt Aggression Scale Subjects monitored and assessed weekly by the treating physician, who was blind to treatment condition, during the first 4 weeks of each fluoxetine/placebo phase of the study. For the remainder of the trial, and during the washout period, patients were monitored every other week. | Inclusion criteria:; - Between 5–17 years old; - Met criteria for ASD on DSM-IV, ADI-R, & ADOS-G – includes autism, Aspergers syndrome, and PDD; - Patients free of psychiatric medications 6 weeks prior to study; Exclusion criteria:; - Diagnosis of DSM-IV psychotic disorders; - History of seizures; - Any clinically significant medical illness; - Concurrent psychotropic medications or cognitive behavioral therapy; - Individuals who were responding well to previous interventions or had only mild global severity; - Subjects unable to tolerate a minimum dose of 2.4 mg/day of liquid fluoxetine; Age, mean/yrs ±SD (range): 8.18 ± 3.04 (5–16) Mental age, mean/yrs (range): NR Gender: M, n (%): 30 (76.9) F, n (%): 9 (23.1) Race/ethnicity, n (%): Caucasian 22 (56.4) Asian 2 (5.1) Black 9 (23.1) Hispanic 6 (15.4) SES: Maternal education: NR Household income: NR Diagnostic approach: In Study | Overall ratings: Global Improvement Scale Adapted to Global Autism (CGIAD), mean ± SD: G1: 4.5 ± 0.84 G2: 4.7 ± 0.9 Educational/ cognitive/ academic attainment: IQ, mean ±SD: G1: 68.1 ± 26.7 G2: 59.2 ± 29.1 Repetitive behavior: Children’s Yale- Brown Obsessive- Compulsion Scale, compulsions subscale (CY- BOCS), mean ± SD: G1: 13.5 ± 2.9 G2: 12.8 ± 2.6 Adaptive behavior: Vineland adaptive behavior composite, mean ± SD: G1: 47.9 ± 19.4 G2: 45.1 ± 24.6 | Overall ratings: CGI-AD, mean ± SD: G1: RCT Week 8: 3.58 ± 0.8 Crossover Week 20: 3.06 ± 1.1 G2: RCT Week 8: 3.42 ± 1.2 Crossover Week 20: 3.19 ± 1.0 CGI-AD not significantly different between intervention and placebo (P = 0.519) Global Composite Improvement (reported at weeks 8 and 20), mean ± SD: G1: RCT Week 8: 3.21 ± 2.6 Crossover Week 20: 1.73 ± 3.6 G2: RCT Week 8: 2.21 ± 3.0 Crossover Week 20: 3.50 ± 3.0 Global Comp improvement trending toward significance ( P = 0.056) Repetitive behavior: CY-BOCS, mean ± SD: G1: RCT Week 0: 13.45 ± 2.9 Week 4: 12.7 ± 3.2 Week 8: 12.95 ± 3.2 Crossover Week 12: 12.93 ± 3.5 Week 16: 11.94 ± 3.4 Week 20: 11.77 ± 3.2
| Adverse effects monitored via the clinician administered FSEC at every visit. CY-BOCS and CGI-AD outcome assessments completed by blinded independent evaluator at baseline and every 4 weeks, until week 20 or termination. Fluoxetine Side Effects Checklist completed by parent with psychiatrist, if able to do so, at each visit. Groups: G1: placebo (RCT)/liquid fluoxetine (crossover) G2: liquid fluoxetine (RCT)/placebo (crossover) Co-interventions held stable during treatment: Yes Frequency of contact during study: Weekly during first 4 weeks of each fluoxetine/placebo phase of the study; every other week during the remainder of the trial and the washout period Concomitant therapies, n (%): No concurrent psychotropic medications or cognitive behavioral therapies were allowed during the study N at enrollment: 45 (G1 and G2 n’s NR) N continuing after randomization: G1: 20 G2: 19 N at follow-up: G1: 18 G2: 16 | Diagnostic tool/method: DSM-IV TR diagnosis by psychiatric interview, ADI- R, ADOS-G, VABS, WPPSI-R, WISC-III, WAIS- III, LIPS-R Diagnostic category, n (%): G1: Autism: 17 (85) Aspergers: 3 (15) G2: Autism: 17 (89.5) Aspergers: 2 (10.5) Other characteristics, n (%): Mentally retarded: 23 (59) | | G2: RCT Week 0: 12.84 ± 2.6 Week 4: 11.05 ± 3.4 Week 8: 11.63 ± 3.8 Crossover Week 12: 12.24 ±3.5 Week 16: 12.13 ± 2.6 Week 20: 12.38 ± 2.4 Fluoxetine superior to placebo on CY- BOCS (P = 0.038) Problem behavior: OAS-M: no trend or significant effect of drug vs placebo on the suicide subscale Fluoxetine: 0 Placebo: 1 Harms, n/N (%): Insomnia: Fluoxetine: 14/39 (35.9) Placebo: 17/36 (47.2) Anxiety/nervousness: Fluoxetine: 6/39 (15.9) Placebo: 12/36 (33.3) Urinary incontinence: Fluoxetine: 4/39 (10.3) Placebo: 7/36 (19.4) Drowsiness/fatigue/ sedation: Fluoxetine: 7/39 (17.9) Placebo: 4/36 (11.1) Agitation: Fluoxetine: 18/39 (46.2) Placebo: 16/36 (44.4 )
| | | | Diarrhea: Fluoxetine: 2/39 (5.1) Placebo: 7/36 (19.4) Weight gain: Fluoxetine: 0/39 (0) Placebo: 1/36 (2.8) Anorexia: Fluoxetine: 6/39 (15.4) Placebo: 4/36 (11.1) Proportion of subjects having dosage reduction on the two treatment due to AEs was not statistically significant (P = 0.289) Modifiers: NR

Howard et al., 2005

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Howard et al., 2005 Country: US Practice setting: Academic Intervention setting: G1: Home, School, and Community G2: School G3: School Enrollment period: 1996–2003 Funding: Valley Mountain Regional Center Region 6 Autism Connection and California State University, Stanislaus Author industry relationship disclosures: NR Design: Prospective cohort | Intervention: Intensive behavior analytic treatment with individualized goals and objectives 25–30 hours/week 1:1 intervention for children <3 years of age and 35– 40 hours/week of 1:1 intervention for children >3 years of age 50–100 learning opportunities/hour via discrete trial, incidental teaching, and other behavior analytic procedures Parents received training in basic behavior analytic strategies and implemented programs with children outside regular intervention hours, with agency staff meeting 1–2 times/month. Assessments Conducted by experienced psychologists and speech and language pathologists who were independent contractors with the local regional center and who were not involved in delivering treatment to any of the children in the study; - BSID-2^nd^ Edition; - WISC-R; - Developmental Profile- II; - SB-FE; - MPS; - RDLS; - VABS-Interview Edition | Inclusion criteria:; - Diagnosed with autistic disorder or PDD-NOS according to DSM-IV criteria by qualified independent examiner prior to 48 months of age; - Entry in an intervention program prior to 48 months of age; - English as primary spoken language in child’s home; - No significant medical condition other than autistic disorder or PDD-NOS; - No prior treatment >100 hours.; - Referred from non-profit agencies (“regional centers’) under contract with CA dept of Developmental services for developmental disability case management; Exclusion criteria: See inclusion criteria Age, mean/months ± SD: At diagnosis: G1: 30.48 ± 5.96 G2: 39.31 ± 5.52 G3: 34.94 ± 5.18 At intake: G1: 30.86 ± 5.16 G2: 37.44 ± 5.68 G3: 34.56 ± 6.53 At follow-up: G1: 45.66 ± 6.24 G2: 50.69 ± 5.64 G3: 49.25 ± 6.81 Mental age: See baseline measures | Intake conducted within 2 months of treatment entry Overall ratings: Composite Standard Scores, mean ± SD: G1: 70.46 ± 11.85 G2: 69.81 ± 10.48 G3: 71.62 ± 10.47 Social skills: Standard Scores, mean ± SD: G1: 72.79 ± 11.26 G2: 75.50 ± 14.25 G3: 75.07 ± 12.09 Age equivalents (months), mean ± SD: G1: 16.39 ± 4.89 G2: 22.06 ± 10.62 G3: 19.60 ± 5.68 Learning rates prior to intake, mean age equivalents per year ± SD: G1: 0.54 ± 0.18 G2: 0.58 ± 0.23 G3: 0.58 ± 0.19 Communication/ language: Standard Scores, mean ± SD: G1: 66.18 ±10.02 G2: 63.69 ± 9.68 G3: 66.20 ± 8.70 Age equivalents (months), mean ± SD: G1: 14.90 ± 4.32 G2: 16.19 + 6.44 G3: 16.53 ± 5.25 Learning rates prior to intake, mean age equivalents per year ± SD: G1: 0.49 ± 0.15 G2: 0.43 ± 0.15 G3: 0.49 ± 0.15 | Follow-up testing conducted at an average 14 months after treatment entry Overall ratings: Composite Standard Scores, mean ± SD: G1: 81.32 ± 11.14 (P < 0.01 compared to G2/G3 mean) G2: 69.25 ± 12.91 G3: 68.25 ± 9.86 Social skills: Standard Scores, mean ± SD: G1: 82.08 ± 11.73 (P < 0.01 compared to G2/G3 mean) G2: 75.00 ± 18.01 G3: 70.56 ± 11.77 Age equivalents (months), mean ± SD: G1: 32.04 ± 10.23 (P < 0.05 compared to G2/G3 mean) G2: 30.06 ± 16.10 G3: 24.81 ± 7.23 Learning rates between intake and follow-up, mean age equivalents per year ± SD: G1: 1.04 ± 0.74 (P < 0.05 compared to G2/G3 mean) G2: 0.60 ± 0.94 G3: 0.40 ± 0.67
| Other (received by few children):; - DAS; - Development Assessment of Young Children; - PEP-R; - LIPS; - PPVT-III; - Expressive Vocabulary Test; - Sequenced Inventory of Communication Development-Revised; - PLS-3; - Rossetti Infant-Toddler Language Scale; - Receptive-Expressive Emergent Language Scales-Revised; - EOWPVT; - ROWPVT; - Denver Developmental Screening Test II; - Rockford Infant Development Evaluation Scales; Groups: G1: intensive behavior analytic intervention G2: intensive eclectic treatment G3: non-intensive public early intervention | Gender: G1: M, n (%): 25 (86) F, n (%): 4 (14) G2: M, n (%): 13 (81) F, n (%):3 (19) G3: M, n (%): 16 (100) F, n (%): 0 (0) Race/ethnicity, n (%): G1: Both parents Caucasian: 21 (72) One or both parents Hispanic: 4 (14) Other: 4 (14) G2: (percents only account for known) Both parents Caucasian: 6 (50) One or both parents Hispanic: 3 (25) Other: 3 (25) Unknown: 4 (33) G3: (percents only account for known) Both parents Caucasian: 8 (57%) One or both parents Hispanic: 4 (29) Other: 2 (14) Unknown: 2 (17) SES: Maternal education, mean ± SD: G1: 14.10 ± 2.34 G2: 13.00 ± 1.83 G3: 13 ± 1.41 Paternal education, mean ± SD: G1: 14.62 ± 2.77 G2: 13.13 ± 2.56 G3: 13.00 ± 1.81 Parents’ education, mean ± SD G1: 14.36 ±2.22 G2: 13.06 ± 1.82 G3: 12.97 ± 1.36 Diagnostic approach: Referral | Receptive: Standard Scores, mean ± SD: G1: 52.16 ± 18.44 G2: 45.38 ± 14.97 G3: 49.00 ± 13.61 Age equivalents (months), mean ± SD: G1: 14.57 ± 5.82 G2: 16.81 ± 5.36 G3: 16.60 ± 5.34 Learning rates prior to intake, mean age equivalents per year ± SD: G1: 0.48 ± 0.21 G2: 0.45 ± 0.15 G3: 0.48 ± 0.12 Expressive: Standard Scores, mean ± SD: G1: 51.88 ±12.91 G2: 43.88 ± 6.69 G3: 48.77 ± 11.61 Age equivalents (months), mean ± SD: G1: 14.76 ± 4.72 G2: 16.38 ± 2.99 G3: 17.87 ± 5.45 Learning rates prior to intake, mean age equivalents per year ± SD: G1: 0.49 ± 0.16 G2: 0.44 ± 0.06 G3: 0.53 ± 0.17 Motor skills: Standard Scores, mean ± SD: G1: 95.11 ± 11.70 G2: 93.19 ± 10.10 G3: 92.08 ± 13.84 Age equivalents (months), mean ± SD: G1: 28.86 ± 5.86 G2: 33.56 ± 7.20 G3: 32.00 ± 6.25 | Communication/ language: Standard Scores, mean ± SD: G1: 85.44 ± 14.73 (P < 0.01 compared to G2/G3 mean) G2: 64.13 ± 14.18 G3: 68.69 ± 14.18 Age equivalents (months), mean ± SD: G1: 36.60 ± 12.23 (P < 0.01 compared to G2/G3 mean) G2: 23.88 ± 11.82 G3: 26.13 ± 8.74 Learning rates between intake and follow-up, mean age equivalents per year ± SD: G1: 1.43 ± 0.72 (P < 0.01 compared to G2/G3 mean) G2: 0.56 ± 0.76 G3: 0.69 ± 0.70 Receptive: Standard Scores, mean ± SD: G1: 71.31 ± 22.72 (P < 0.05 compared to G2/G3 mean) G2: 49.93 ± 19.62 G3: 49.21 ± 16.08 Age equivalents (months), mean ± SD: G1: 2.23 ± 10.04 (P < 0.05 compared to G2/G3 mean) G2: 26.27 ± 11.56 G3: 25.38 ± 10.00
| Provider:; - G1: 4–5 instructional assistants attending college trained and supervised by staff w/ masters degrees in psychology or special ed and experience in ABA with children with autism. Some supervisors assisted by staff with bachelor’s degrees and graduate coursework in behavior analysis. Supervisors worked under direction of a Board Certified Behavior Analysis who was also a licensed psychologist and a licensed speech and language pathologist.; - G2: classroom teachers received consultation from staff with 1–2 years graduate coursework in behavior analysis; - G3: special education teachers or certified speech and language pathologists who supervised 1–2 paraprofessional aides; Measure of treatment fidelity reported: No Co-interventions held stable during treatment: No for G1 G2: individual or small group speech therapy sessions G3: individual or small group speech therapy sessions Concomitant therapies, n (%): Speech/language therapy: G2: 7 (44) G3: 13 (81) | Diagnostic tool/method: DSM-IV Diagnostic category, n (%): G1: Autism: 24 (83) PDD-NOS: 5 (17) G2: Autism: 12 (75) PDD-NOS: 4 (25) G3: Autism: 9 (56) PDD-NOS: 7 (44) Other characteristics: Severity of autism (number of DSM-IV criteria), mean ± SD G1: 7.55±1.39 G2: 7.27±1.56 G3: 7.33±2.02 Marital status, n (%): G1: Married: 23 (79) Not married, divorced or Separated: 6 (21) G2: (percent only for known) Married: 12 (80) Not married, divorced or Separated: 3 (20) Unknown: 1 (7) G3: Married: 9 (56) Not married, divorced or Separated: 7 (44) | Learning rates prior to intake, mean age equivalents per year ± SD: G1: 0.95 ± 0.18 G2: 0.90 ± 0.13 G3: 0.93 ± 0.18 Educational/ cognitive/ academic attainment: Standard Scores, mean ± SD: G1: 58.84 ± 18.15 G2: 53.69 ± 13.50 G3: 59.88 ± 14.85 Age equivalents (months), mean ± SD: G1: 17.04 ± 6.07 G2: 17.27 ± 4.71 G3: 17.10 ± 3.93 Non-verbal: Standard Scores, mean ± SD: G1: 80.14 ± 11.86 G2: 67.44 ± 16.69 G3: 77.69 ± 12.33 Age equivalents (months), mean ± SD: G1: 24.43 ± 4.37 G2: 24.75 ± 6.01 G3: 26.83 ± 6.95 Learning rates prior to intake, mean age equivalents per year ± SD G1: 0.79 ± 0.14 G2: 0.67 ± 0.17 G3: 0.78 ± 0.12 Adaptive behavior: Self-Help: Standard Scores, mean ± SD: G1: 70.71 ± 10.14 G2: 68.06 ± 11.61 G3: 73.43 ± 10.39 | Learning rates between intake and follow-up, mean age equivalents per year ± SD: G1: 1.23 ± 0.56 (P < 0.01 compared to G2/G3 mean) G2: 0.65 ± 0.47 G3: 0.48 ± 0.43 Expressive: Standard Scores, mean ± SD: G1: 70.46 ± 22.88 (P < 0.05 compared to G2/G3 mean) G2: 47.67 ± 23.39 G3: 46.79 ± 12.81 Age equivalents (months), mean ± SD: G1: 31.96 ± 12.00 (P < 0.05 compared to G2/G3 mean) G2: 24.00 ± 12.02 G3: 23.31 ± 7.36 Learning rates between intake and follow-up, mean age equivalents per year ± SD: G1: 1.22 ± 0.73 (P < 0.01 compared to G2/G3 mean) G2: 0.49 ± 0.78 G3: 0.33 ± 0.45 Motor skills: Standard Scores, mean ± SD: G1: 98.16 ± 12.01 (P < 0.05 compared to G2/G3 mean) G2: 88.06 ± 13.43 G3: 89.50 ± 10.06
| N at enrollment: G1: 37 G2+G3: 41 N at follow-up: G1: 29 G2: 16 G3: 16 Number of children varies per follow-up measure | | Age equivalents (months), mean ± SD: G1: 18.24 ±3.83 G2: 21.44 ± 7.78 G3: 21.20 ± 6.67 Learning rates prior to intake, mean age equivalents per year ± SD: G1: 0.61 ± 0.17 G2: 0.57 ± 0.16 G3: 0.62 ± 0.18 | Age equivalents (months), mean ± SD: G1: 44.16 ± 8.22 (P < 0.05 compared to G2/G3 mean) G2: 43.00 ± 7.28 G3: 42.25 ± 6.58 Learning rates between intake and follow-up, mean age equivalents per year ± SD: G1: 0.99 ± 0.45 G2: 0.69 ± 0.49 G3: 0.83 ± 0.59 Educational/ cognitive/ academic attainment: Standard Scores, mean ± SD: G1: 89.88 ± 20.87 (P < 0.01 compared to G2/G3 mean) G2: 62.13 ± 19.63 G3: 68.81 ± 15.32 Non-verbal: Standard Scores, mean ± SD: G1: 101.67 ±1 9.14 (P < 0.01 compared to G2/G3 mean) G2: 73.56 ± 24.94 G3: 82.53 ± 16.76 Age equivalents (months), mean ± SD: G1: 44.54 ± 8.76 (P < 0.05 compared to G2/G3 mean) G2: 37.38 ± 13.14 G3: 40.80 ± 9.97
| | | | Learning rates between intake and follow-up, mean age equivalents per year ± SD: G1: 1.44 ± 0.52 (P < 0.01 compared to G2/G3 mean) G2: 0.87 ± 0.74 G3: 0.90 ± 0.39 Adaptive behavior: Self-Help: Standard Scores, mean ±SD: G1: 76.56 ± 11.59 (P < 0.01 compared to G2/G3 mean) G2: 70.00 ± 11.92 G3: 65.19 ± 8.84 Age equivalents (months), mean ± SD: G1: 31.88 ± 8.74 (P < 0.05 compared to G2/G3 mean) G2: 31.75 ± 9.75 G3: 27.81 ± 5.75 Learning rates between intake and follow-up, mean age equivalents per year ± SD: G1: 0.91 ± 0.58 (P < 0.05 compared to G2/G3 mean) G2: 0.74 ± 0.80 G3: 0.48 ± 0.49 Difference in Change scores: Values are G1 minus G2/G3 mean change scores:
| | | | Standard scores, mean: Cognitive: 21.03 P < 0.01 Non-verbal: 16.16 P < 0.01 Receptive: 19.97 P < 0.01 Expressive: 19.78 P < 0.05 Communication: 15.88 P < 0.01 Self-help : 8.35 P < 0.05 Social: 10.43 P < 0.05 Motor: 4.75 P = NS Composite: 12.07 P < 0.01 Age equivalents, mean/months: Non-verbal: 7.95 P < 0.01 Receptive: 9.04 P < 0.01 Expressive: 10.66 P < 0.01 Communication: 12.42 P < 0.01 Self-help: 4.76 P < 0.05 Social: 8.78 P < 0.01 Motor: 3.97 P = NS Learning rates (age equivalents per year), mean: Non-verbal: 0.49 P < 0.05 Receptive: 0.64 P < 0.01 Expressive: 0.79 P < 0.01 Communication: 0.76 P < 0.01 Self-help: 0.28 P < 0.05 Social: 0.56 P < 0.05
| | | | Motor: 0.17 P = NS Harms: NR Modifiers: NR

Mahoney et al., 2005

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Mahoney et al., 2005 Country: US Practice setting: Academic Intervention setting: Home or Center-based Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: Prospective case series | Intervention: Relationship-Focused (RF) intervention using Responsive Teaching (RT) curriculum Weekly 1 hr parent-child sessions for 1 year Assessments: Child & family data collected at the beginning & end of intervention. Trans-disciplinary Play-Based assessment, ITSEA to assess socio-emotional behavior and TABS for problem behavior. Both parents responded to instruments. CBRS to rate child’s Pivotal behavior and MBRS to assess parents’ style of interaction. Groups: G1: pervasive development disorder – not otherwise specified Provider: Early intervention specialists Children received RT on an average of 32.6 ± 12.9 sessions Hours/week of intervention activities at home: 15.1± 2.4 Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 20 | Inclusion criteria:; - Children with either PDD /other developmental disabilities (DD) with age ranging from 12–54 months; - Meeting the DSM-IV criteria for PDD; Exclusion criteria: See inclusion criteria Age, mean/months ± SD: G1: 32.4 ± 7.3 Mental age: NR Gender: M, %: G1: 65 F, %: G1: 35 Race/ethnicity, %: White: G1: 95.2 SES: Education, mean/yrs ± SD : Maternal: G1: 15.5 ± 2.6 Paternal: G1: 15.9 ± 2.6 Married, n (%): G1: 20 (100) Employment, %: Employed: G1: 52.1 Part time: G1: 28.6 Full time: G1: 23.8 Household income: NR Diagnostic approach: In Study: Diagnosed by physicians Diagnostic tool/method: DSM-IV | Social skills: Socio-emotional Functioning: ITSEA, mean ± SD: Internalizing: G1: 49.5 ± 8.1 Externalizing: G1: 47.9 ± 8.6 Self-regulation: G1: 41.3 ± 8.6 Social competence: G1: 30.2 ± 15.8 Communication/language: Trans-disciplinary Play-Based Assessment, mean ± SD: Object relations: G1: 16.5 ± 6.0 Symbolic behavior: G1: 15.2 ± 5.3 Expressive language: G1: 13.8 ± 6.7 Receptive language: G1: 12.1 ± 7.2 Problem behavior: Temperament Atypical Behavior Scale (TABS) mean ± SD: Detached: G1: 21 ± 21.1 Hypersensitivity/hyperactivity : G1: 39.7 ± 15.0 Under reactivity: G1: 34.7 ± 16.3 Self-regulation: G1: 33.8 ± 16.3 Overall: G1: 55.1 ± 37.3 | Social skills: Socio-emotional Functioning: ITSEA, mean ± SD: Internalizing: G1: 52.9 ± 8.8 P < 0.05 Externalizing: G1: 49 ± 9 Self-regulation: G1: 47.2 ± 7.8 Social competence: G1: 36.6 ± 11.4 Communication/language: Trans-disciplinary Play-Based Assessment, mean ± SD: Expected: Object relations: G1: 22.1 ± 7.4 Symbolic behavior: G1: 20.3 ± 6.6 Expressive language: G1: 18.4 ± 8.6 Receptive language: G1: 16.1 ± 9.1 Observed: Object relations: G1: 27.5 ± 8.2 PCI: G1: 2.2 Symbolic behavior: G1: 24.9 ± 10.0 PCI: G1: 2.03 Expressive language: G1: 24.1 ± 10.2 PCI: G1: 3.36
| N at follow-up: G1: 20 | Diagnostic category, n (%): PDD-NOS : G1: 20 (40) Other characteristics, n: G1: Autism: 10 Autism + mental retardation: 3 PDD: 7 | Adaptive behavior: Child Behavior Rating Scale (CBRS), mean ± SD: Attention: G1: 2.9 ± 1.2 Persistence: G1: 2.9 ± 1.3 Interest: G1: 2.2 ± 1.1 Cooperation: G1: 2.1 ± 0.9 Initiation: G1: 2.7 ± 1.5 Joint attention: G1: 1.9 ± 1.0 Affect: G1: 3.3 ± 0.8 Maternal Behavioral Rating Scale (MBRS), mean ± SD: Responsiveness: G1: 2.7 ± 0.7 Affect: G1: 2.8 ± 0.6 Achievement orientation: G1: 3 ± 0.6 Directiveness: G1: 3.2 ± 0.5 | Receptive language: G1: 22.9 ± 8.4 PCI: G1:3.59 Children made greater improvements in object relations and receptive language and in all 4 developmental measures Problem behavior: Temperament Atypical Behavior Scale (TABS), mean ± SD: Detached: G1: 35.2 ± 22.0 Hypersensitivity/hyperactivity: G1: 43.6 ± 13.7 Under reactivity: G1: 47.1 ± 13.6 Self-regulation: G1: 43.6 ± 11.5 Overall: G1: 75.4 ± 38.5
| | | | Children with PDDs made improvements in 3 subscales (self-regulation, detached, underactivity) as well as on the overall TABS scores which increased by an average of 1.5 SD Adaptive behavior: Child Behavior Rating Scale (CBRS), mean ± SD: Attention: G1: 4.1 ± 0.7 Persistence: G1: 4.5 ± 0.8 Interest: G1: 3.8 ± 0.8 Cooperation: G1: 3.5 ± 0.9 Initiation: G1: 4.2 ± 0.7 Joint attention: G1: 3.6 ± 1.0 Affect: G1: 4.1 ± 0.7 Maternal Behavioral Rating Scale (MBRS), mean ± SD: P < 0.001 Responsiveness: G1: 3.8 ± 0.5 Affect: G1: 3.5 ± 0.5 Achievement orientation: G1: 2.9 ± 0.4 Directiveness: G1: 3.1 ± 0.3
| | | | Mothers of children with PDD made increases in responsiveness and affect Each of the behaviors measured by CBRS increased during intervention and showed improvement on all items The pivotal behavior both at the start and during the intervention did not significantly contribute to the socio-emotional measures Harms: NR Modifiers: NR

McConachie et al., 2005

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: McConachie et al., 2005 Country: UK Practice setting: Academic Intervention setting: Home Enrollment period: NR Funding: Community Fund (National Lottery Charities Board), The NHS Executive R&D Northern and Yorkshire Region (for training course leaders) Author industry relationship disclosures: NR Design: Non randomized controlled trial | Intervention: More Than Words course to improve parents’ skills in social interaction with child and improve communication with child The More Than Words course lasted 3 months with weekly group instruction sessions (totaling 20 hours) and 3 home visits for individual discussion/feedback Interval between assessments, months ± SD: G1: 8.65 ± 1.50 G2: 5.16 ± 1.31 Assessments: Pre-treatment and at 7 months: VABS, MCDI, ADI-R, ADOS, BSQ assessments conducted in home by study psychologist; Joy and Fun assessment (unpublished checklist created for study to document positive parent strategies), QRSF, PFQ by parents Groups: G1: More Than Words G2: waitlist control Ga: autism diagnosis Gb: NCA diagnosis Provider: Developmental psychologist (second author) Measure of treatment fidelity reported: Yes Co-interventions held stable during treatment: Yes Concomitant therapies, n (%): G1: 17 (65.4) G2: 16 (61.5) | Inclusion criteria:; - Child Identified by the local community pediatrician or speech and language therapist as having language delay and some aspect of concern about social behavior that raised the suspicion of ASD; - Age 24–48 months; - Parents agreed to attend More than Words course; Exclusion criteria:; - Serious organic medical disorder; - About to start an intensive home program; Age, months ± SD: G1: 38.12 ± 6.54 G2: 34.96 ± 6.68 Mental age: NR Gender, n (%): Male: G1: 21 (81) G2: 21 (84) Female: G1: 25 (19) G2: 4 (16) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral, confirmed in Study Diagnostic tool/method: ADOS Diagnostic category, n (%): Autism: G1: 17 (65) G2: 12 (48) NCA: G1: 9 (35) G2: 13 (52) | Communication/language: MCDI total speech production score, mean ± SD: G1a: 34.65 ± 62.74 G1b: 188.22 ± 159.18 G2a: 30.75 ± 54.35 G2b: 77.54 ± 79.22 Social Skills: ADOS reciprocal social interaction and communication score, mean ± SD: G1a: 17.35 ± 2.45 G1b: 4.33 ± 2.78 G2a: 17.17 ± 3.76 G2b: 7.15 ± 5.24 Problem behavior: BSQ score, mean ± SD: G1a: 11.59 ± 4.70 G1b: 9.33 ± 4.21 G2a: 12.42 ± 3.94 G2b: 9.31 ± 3.71 Joy and Fun assessment score, mean ± SD G1a: 11.18 ± 4.30 G1b: 10.89 ± 2.98 G2a: 10.83 ± 3.86 G2b: 12.85 ± 3.91 Adapted QRS-F score, mean ± SD: G1a: 19.53 ± 9.50 G1b: 18.44 ± 9.88 G2a: 19.60 ± 5.32 G2b: 15.08 ± 8.63 Parent Feelings Questionnaire score, mean ± SD: G1a: 145.00 ± 20.40 G1b: 150.33 ± 26.06 G2a: 146.36 ± 18.35 G2b: 159.31 ± 22.36 | Communication/language: MCDI total speech production score, mean ± SD: G1a: 72.6 ± 100.07 G1b: 271.38 ± 148.43 G2a: 38.92 ± 54.89 G2b: 131.54 ± 114.7 G1a/BL: P < 0.05 G1b/BL: P < 0.05 G2a/BL: P < 0.05 G2b/BL: P < 0.05 G2a/G1a: P = 0.019 G2b/G2a: P < 0.001 Social skills: ADOS reciprocal social interaction and communication score, mean ± SD: G1a: 14.82 ± 6.47 G1b: 6.00 ± 3.87 G2a: 14.00 ± 6.45 G2b: 7.69 ± 5.84 G1a/BL: P = NS G1b/BL: P = NS G2a/BL: P = NS G2b/BL: P = NS G2a/G1a: P = NS G2b/G2a: P = NS Problem behavior: BSQ score, mean ± SD: G1a: 12.50 ± 5.05 G1b: 8.44 ± 3.40 G2a: 12.92 ± 4.10 G2b: 9.23 ± 3.98 G1a/BL: P = NS G1b/BL: P = NS G2a/BL: P = NS G2b/BL: P = NS G2a/G1a: P = NS G2b/G2a: P = NS
| N at enrollment: G1: 26 G1a: 17 G1b: 9 G2: 21 G2a: 12 G2b: 13 N at follow-up: G1: 26 G1a: 17 G1b: 9 G2: 21 G2a: 12 G2b: 13 | Other characteristics: VABS composite score, mean ± SD: G1: 66.42 ± 11.44 G2: 67.76 ± 9.81 | | Joy and Fun assessment score, mean ± SD: G1a: 13.94 ± 4.68 G1b: 11.11 ± 3.44 G2a: 11.58 ± 4.54 G2b: 13.77 ± 3.49 G1a/BL: P < 0.05 G1b/BL: P = NS G2a/BL: P < 0.05 G2b/BL: P = NS G2a/G1a: P = 0.05 G2b/G2a: P = NS Harms: NR Modifiers: NR
Author: RUPP, 2005 Country: US Practice setting: Academic centers Intervention setting: Clinic Enrollment period: June 1999 to April 2001 Funding: NIH; Kor-czak Foundation; Janssen (provided study medication) Author industry relationship disclosures: NR Design: Open label extension phase followed by RCT discontinuation phase | Intervention: Part 1: 4 month open-label Rx with Risperidone, starting at the optimal dose Part 2: 8 week randomized double-blind gradual placebo-substitution for risperidone Open label extension phase intervention (16 weeks): Responders from the RCT or the extension trial were invited to continue into the open label extension Clinicians were allowed to adjust the total daily dose according to response and side effects, up to a maximum of 3.5 mg/day for children weighing 15–45 kg and up to 4.5 mg/ day for children > 45 kg Last values were carried forward for individuals not completing this phase Mean risperidone dose at week 0= 1.96 mg/day. Mean risperidone dose at week 16=2.08 mg/day (6% increase over 4 month period) Randomized discontinuation phase (8 weeks): Participants randomized to risperidone or placebo. Placebo group had risperidone replaced by placebo by 25% each week for the first four weeks; enrollment halted after 32 participants were randomized (interim safety review indicated significantly increased relapse rate among placebo vs. risperidone treated patients | Inclusion criteria:; - Children meeting DSM-IV criteria for autistic disorder, with tantrums, aggression, self-injurious behavior, or a combination of these problems; - Aged 5 to 17 years; - Weight ≥ 15 kg; - Mental age ≥ 18 months; - Clinically significant behavioral problems with clinician-determined rating of ≥ moderate on CGI-S and score ≥ 18 on ABC Irritability subscale rated by parent and confirmed by caregiver (children reassessed at baseline, 7–14 days after initial assessment to confirm first values); Exclusion criteria:; - Serious medical disorders; - Other psychiatric disorders requiring medication; - Children receiving a psychotropic drug that was deemed effective for the treatment of aggression, tantrums, or self-injurious behavior; Age, years (mean ± sd): 8.6 ± 2.8 (5–17), n=63 Mental age: Mental development, n (%): IQ: Average or above average: 3 (4.8) Borderline: 7 (11.1) Mild retardation: 17 (27) Moderate: 12 (19) Severe: 11 (17.5) Profound: 7 (11.1) Unable to assess: 6 (9.5) Gender: n (%): Male: 49 (77.8) | Overall ratings: Extension phase: (end of initial 8 weeks of medication exposure) : (n=63) ABC-C, mean ± SD: Irritability: G1: 9.5 ± 6.8 Social withdrawal: G1: 7.3 ± 5.4 Stereotypy: G1: 4.9 ± 4.3 Hyperactivity: G1: 15.1 ± 10 Inappropriate speech: G1: 3.4 ± 3.6 CGI Improvement score, n (%): G1: Very much improved: 19 (30.2) Much improved: 42 (66.7) Minimally improved: 0 (0.0) No change: 2 (3.2) Worse: 0 (0.0) Much worse: 0 (0.0) Discontinuation phase participants, mean ± SD: (n=38) ABC-hyperactivity: 34.4 ± 8.7 ABC-Irritability: 27.6 ± 6.1 | 4- month open label extension phase: ABC-C, mean ± SD: Irritability: G1: 11.7 ± 8 ; F = 5.35, P = 0.028 Lethargy / social withdrawal: G1: 6.8 ± 5.9; F = 2.61, P = NS Stereotypy: G1: 5.8 ± 4.7; F = 5.47, P = 0.02 Hyperactivity: G1: 15.8 ± 10.2; F = 0.43, P = NS Inappropriate speech: G1: 3.4 ± 3.2 ; F = 0.39, P = NS CGI Improvement score, n (%) G1: Very much improved: 19 (30.2) Much improved: 33 (52.4) Minimally improved: 6 (9.5) No change: 0 (0.0) Worse: 3 (4.8) Much worse: 2 (3.2) RCT participants: Relapse during discontinuation phase, n (%): G1: 2/16 (12.5) G2: 10/16 (62.5) G1/G2: P = 0.01 Time to relapse, discontinuation phase, median days: G1: 57 G2: 34 Harms (n=63), %: Nasal congestion: 11.1 Appetite increase: 7.9 Coughing: 6.3
| Assessments: Intelligence testing, Lab tests, ECGS, at entry into the extension phase and prior to the discontinuation phase VABS maladaptive behavior at entry to the open label extension phase Vital signs, height, weight at each visit Neurological side effects done by Simpson – Angus Rating scale and AIMS. medical history, physical examination Clinician rated CGI and monthly scores on the parent rated subscales of ABC-C weekly assessment in the discontinuation phase Groups: Open label extension phase: G1: risperidone Discontinuation phase: G1: risperidone G2: placebo Co-interventions held stable during treatment: NR Concomitant therapies: NR N at start of extension phase: G1: 63^*^ N at end of extension phase: G1: 51 N at enrollment of discontinuation phase: Total: 38 N at end of discontinuation phase: G1: 16 G2: 16 | Race/ethnicity, RCT population, n (%): White: 44 (69.8) Black: 6 (9.5) Hispanic: 3 (4.8) Asian or Pacific islander: 4 (6.3) Other: 6 (9.5) SES: Education of parent or primary caregiver, n (%): Less than high school: 1 (1.6) High school: 13 (20.6) Trade or Technical school: 4 (6.3) At least some college: 35 (55.6) Advanced degree: 10 (15.9) Annual household income, n (%): < $20,000: 6 (9.5) $20,001–$40,000: 17 (27) $40,001–$60,000: 15 (23.8) > $60,000: 23 (36.5) Diagnostic approach: In Study Diagnostic tool/method: Diagnosis corroborated by ADI-R, administered by a clinician with special training and systematic review to ensure reliability Diagnostic category: See inclusion criteria Other characteristics, n (%): Educational placement of child: (n=63) Regular class: 4 (6.3) Special education program: 47 (74.6) Special school: 11 (17.5) Residential school: 0 Other: 1 (1.6) Current anticonvulsant treatment: n (%): 1/63 (1.6) | | Anxiety, Difficulty falling asleep, Fever, Skin irritation, Vomiting: 4.8 Accidental injury, Constipation, Drowsiness/sedation, Enuresis, Headache, Hypersalivation, Sore throat: 3.2 Depression, Diarrhea, Difficulty urinating, Dyskinesia, Earache, Restlessness/agitation, Sinus condition, Stomach/abdominal discomfort, Tiredness/fatigue, Tremor, Weight gain, Muscle rigidity, Other: 1.6 Modifiers: No predictors of relapse were identified
| | Previous medication (n=63): Medication naïve: 11 (17.7) Antipsychotic agent: 4 (6.5) SSRI: 9 (14.5) Stimulant: 16 (25.8) Alpha-2 agonist: 11 (17.7) Child living at home with at least 1 parent: 56 (88.9%)

Sallows et al., 2005

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Sallows et al., 2005 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: 1996 to 1997 Funding: NIH Author industry relationship disclosures: NR Design: RCT | Intervention: Intensive clinic-directed vs. less intensive parent-directed groups using treatment based on UCLA model (without aversives and the addition of procedures from subsequent approaches) Clinic-directed treatment parents had 6–10 hours/ week of 2–3 hour in-home consultation sessions with a senior therapist, team meetings for 1 hour per week, and an hour-long progress review per week for 1–2 years and every other month thereafter; parent-directed treatment had one 3 hour consultation session with a senior therapist every 2 weeks, team meetings for 1 hour every 1–2 weeks, and an hour-long progress review every other month Duration: 4 years Frequency, 1:1 direct treatment, hours/week ± SD: Year 1: G1: 38.60 ± 2.91 G2: 31.67 ± 5.81 Year 2: G1: 36.55 ± 3.83 G2: 30.88 ± 4.04 Assessments: BSID, Merrill-Palmer scales, RDLS, VABS communication, daily living and socials skills, WASI, WISC-III, Leiter R, Clinical Evaluation of Language Fundamentals administered by invest-tigator or independent psychologist at pretreatment and annually for 4 years | Inclusion criteria:; - Recruited through local birth-3 special education programs; - Age 24–42 months at intake; - Ratio estimate of mental age/chronological age by Mental Development Index ≥ 35; - Neurologically within “normal” limits as determined by a pediatric neurologist; - Diagnosis of autism by independent child psychiatrists familiar with autism and known for their experience; - Met DSM-IV criteria for autism as determined by trained examiner; Exclusion criteria:; - See inclusion criteria; Age, months ± SD: Pre-test: G1: 33.23 ± 3.89 G2: 34.20 ± 5.06 During treatment: G1: 35.00 ± 4.86 G2: 37.10 ± 5.36 Post-test: G1: 83.23 ± 8.92 G2: 82.50 ± 6.61 Mental age: See baseline measures Gender, n (%): Male: G1: 11 (84.6) G2: 8 (80) Female: G1: 2 (15.4) G2: 2 (20) Race/ethnicity: NR SES: Maternal education to BA level, n (%): G1: 9/12 (75) G2: 9/10 (90) | Educational/ cognitive/ academic attainment: FSIQ, mean ± SD G1: 50.85 ± 10.57 G2: 52.10 ± 8.98 Ga: 55.27 ± 8.96 Gb: 47.83 ± 9.37 Nonverbal IQ, mean ± SD: G1: 70.58 ± 16.54 G2: 82.67 ± 14.94 Ga: 83.56 ± 14.84 Gb: 69.83 ± 15.93 Communication/language: VABS communication score, mean ± SD G1: 57.46 ± 4.97 G2: 63.20 ± 5.58 Ga: 60.82 ± 4.02 Gb: 59.17 ± 7.22 RDLS score, mean ± SD: Receptive language: G1: 38.85 ± 6.09 G2: 38.78 ± 6.44 Ga: 39.30 ± 6.91 Gb: 38.42 ± 5.59 Expressive language: G1: 47.92 ± 6.17 G2: 48.44 ± 6.96 Ga: 49.90 ± 7.75 Gb: 47.50 ± 6.54 Adaptive behavior: VABS score, mean ± SD: Daily living skills: G1: 63.92 ± 5.53 G2: 64.20 ± 3.68 Ga: 66.45 ± 4.25 Gb: 61.83 ± 4.20 Composite: G1: 59.54 ± 5.31 G2: 60.90 ± 5.94 Ga: 61.73 ± 4.59 Gb: 58.67 ± 6.09 | Educational/cognitive/academic attainment: FSIQ, mean ± SD G1: 73.08 ± 33.08 G2: 79.60 ± 21.80 Ga: 103.73 ± 13.35 Gb: 50.42 ± 6.98 Ga/BL: P < 0.01 Gb/BL: P = NS ANOVA: time (P < 0.01)^*^ Verbal IQ, mean ± SD: G1: 78.00 ± 33.48 G2: 76.30 ± 26.66 Ga: 101.45 ± 18.72 Gb: 47.44 ± 2.06 Ga/BL: P < 0.01 Gb/BL: P = NS ANOVA: time (P < 0.01)^*^ PIQ, mean ± SD: G1: 84.90 ± 25.86 G2: 90.70 ± 20.72 Ga: 107.55 ± 9.44 Gb: 63.67 ± 8.43 Ga/BL: P < 0.01 Gb/BL: P < 0.01 ANOVA: time (P < 0.01)^*^ Nonverbal IQ, mean ± SD G1: 77.58 ± 25.24 G2: 89.44 ± 18.35 Ga: 108.78 ± 10.96 Gb: 67.70 ± 12.35 Ga/BL: P = NS Gb/BL: P = NS ANOVA: time (P = NS)^*^
Author: Sallows et al., 2005 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: 1996 to 1997 Funding: NIH Author industry relationship disclosures: NR Design: RCT | ADI-R administered by investigator/psychologist and Personality Inventory for Children completed by parent after 3 years treatment Child Behavior Checklist and VABS completed by parents and teachers after 4 years treatment; teachers administered Woodcock Johnson III tests of Achievement for subjects at age 7 in regular education classes UCLA Early Learning Measure administered in first 6 months of treatment by investigator Groups: G1: clinic-directed G2: parent-directed Ga: rapid learners by Early Learning Measure Gb: moderate learners by Early Learning Measure Provider: 18 or older with minimum of 1 year college and 30 hours of training Measure of treatment fidelity reported: Yes Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 13 G2: 11 N at follow-up: G1: 13 G1a: 5 G1b: 8 G2: 10 G2a: 6 G2b: 4 | Paternal education to BA level, n (%): G1: 10/12 (83.3) G2: 6/9 (66.7) Household income, median (range): G1: $62,000 ($35,000–$100,000+) G2: $59,000 ($30,000–$100,000+) Diagnostic approach: See inclusion criteria Diagnostic tool/method: DSM-IV Diagnostic category, n (%): Autism: 23 (100) PDD-NOS: 0 Aspergers: 0 Other characteristics: One-parent families, n (%): G1: 0/13 (0) G2: 1/10 (10) Number of siblings, mean: G1: 2 G2: 2 Non-verbal, n (%): G1: 8/13 (62) G2: 2/10 (20) | Social skills: VABS socialization score, mean ± SD: G1: 58.38 ± 6.17 G2: 60.30 ± 5.76 Ga: 61.55 ± 6.58 Gb: 57.08 ± 4.63 ADI-R score, mean ± SD: Social skills: G1: 17.54 ± 3.73 G2: 18.90 ± 1.14 Ga: 16.45 ± 3.26 Gb: 19.67 ± 1.55 Communication: G1: 12.85 ± 2.44 G2: 12.90 ± 1.22 Ga: 11.00 ± 3.54 Gb: 13.75 ± 0.60 Repetitive behavior: ADI-R ritualistic score, mean ± SD: G1: 5.38 ± 1.69 G2: 6.40 ± 1.11 Ga: 5.91 ± 1.62 Gb: 5.92 ± 1.44 | Personality Inventory for Children, parent rated, cognitive development score, mean ± SD: Ga: 64.18 ± 13.65 Gb: 97.55 ± 18.77 Ga/Gb: P < 0.01 Child Behavior Checklist, parent rated, thought problems score, mean ± SD: Ga: 65.64 ± 9.87 Gb: 70.42 ± 7.92 Ga/Gb: P = NS Communication/language: VABS communication score, mean ± SD: G1: 73.69 ± 32.32 G2: 81.40 ± 24.33 Ga: 105.09 ± 12.83 Gb: 51.33 ± 10.94 Ga/BL: P < 0.01 Gb/BL: P < 0.05 ANOVA: time (P < 0.05)^*^ VABS communication, teacher rated, mean ± SD: Ga: 94.44 ± 13.97 Gb: 58.58 ± 7.90 Ga/Gb: P < 0.01 RDLS score, mean ± SD: Receptive language: G1: 55.85 ± 36.23 G2: 65.78 ± 25.81 Ga: 93.60 ± 12.64 Gb: 31.83 ± 9.87 Ga/BL: P < 0.01 Gb/BL: P = NS ANOVA: time (P < 0.01)^*^
Author: Sallows et al., 2005 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: 1996 to 1997 Funding: NIH Author industry relationship disclosures: NR Design: RCT | | | | Expressive language: G1: 53.38 ± 31.91 G2: 59.22 ± 25.13 Ga: 85.70 ± 15.07 Gb: 30.83 ± 5.89 Ga/BL: P < 0.01 Gb/BL: P < 0.01 ANOVA: time (P = NS)^*^ ADI-R communication score, mean ± SD: G1: 8.08 ± 6.91 G2: 8.80 ± 7.43 Ga: 2.00 ± 2.73 Gb: 14.81 ± 3.59 Ga/BL: P < 0.01 Gb/BL: P = NS ANOVA: time (P < 0.01)^*^ Adaptive behavior: VABS score, mean ± SD: Daily living skills: G1: 66.23 ± 25.95 G2: 64.20 ± 12.42 Ga: 82.27 ± 16.34 Gb: 49.83 ± 10.61 Ga/BL: P < 0.01 Gb/BL: P < 0.01 ANOVA: time (P = NS)^*^ Composite: G1: 69.00 ± 28.04 G2: 66.70 ± 14.68 Ga: 88.64 ± 15.68 Gb: 49.08 ± 7.76 Ga/BL: P < 0.01 Gb/BL: P < 0.05 ANOVA: time (P < 0.05)^*^
Author: Sallows et al., 2005 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: 1996 to 1997 Funding: NIH Author industry relationship disclosures: NR Design: RCT | | | | Social skills: VABS socialization score, mean ± SD: G1: 73.92 ± 23.49 G2: 68.90 ± 10.11 Ga: 87.73 ± 14.94 Gb: 57.08 ± 6.40 Ga/BL: P < 0.01 Gb/BL: P = NS ANOVA: time (P < 0.01)^*^ VABS socialization score, teacher rated, mean ± SD: Ga: 89.89 ± 18.36 Gb: 61.58 ± 6.02 Ga/Gb: P < 0.01 ADI-R social skills score, mean ± SD: G1: 12.33 ± 10.58 G2: 13.10 ± 9.42 Ga: 4.18 ± 4.37 Gb: 21.18 ± 6.28 Ga/BL: P < 0.01 Gb/BL: P = NS ANOVA: time (P < 0.01)^*^ Personality Inventory for Children, parent rated, social incompetence score, mean ± SD: Ga: 62.36 ± 8.34 Gb: 79.25 ± 9.42 Ga/Gb: P < 0.01 Child Behavior Checklist score, mean ± SD: Withdrawn: Parent rated: Ga: 59.09 ± 6.26 Gb: 58.83 ± 6.27 Ga/Gb: P = NS Teacher rated: Ga: 57.00 ± 7.34 Gb: 64.33 ± 6.03 Ga/Gb: P < P<.01
Author: Sallows et al., 2005 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: 1996 to 1997 Funding: NIH Author industry relationship disclosures: NR Design: RCT | | | | Social problems: Parent rated: Ga: 57.82 ± 7.49 Gb: 61.92 ± 7.35 Ga/Gb: P = NS Teacher rated: Ga: 56.73 ± 6.30 Gb: 58.00 ± 5.57 Ga/Gb: P = NS Repetitive behavior: ADI-R ritualistic score, mean ± SD: G1: 5.08 ± 3.75 G2: 5.60 ± 3.50 Ga: 2.73 ± 2.67 Gb: 7.91 ± 2.47 Ga/BL: P < 0.01 Gb/BL: P < 0.05 ANOVA: time (P = NS)^*^ Problem behavior: Personality Inventory for Children, parent rated, undisciplined/ poor self control score, mean ± SD Ga: 53.45 ± 9.38 Gb: 66.83 ± 12.93 Ga/Gb: P < 0.01 Commonly occurring comorbidities: Child Behavior Checklist score, mean ± SD: Anxious/depressed: Parent rated: Ga: 55.40 ± 6.14 Gb: 51.75 ± 3.06 Ga/Gb: P < 0.05 Teacher rated: Ga: 55.90 ± 6.93 Gb: 55.17 ± 6.56 Ga/Gb: P = NS
Author: Sallows et al., 2005 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: 1996 to 1997 Funding: NIH Author industry relationship disclosures: NR Design: RCT | | | | Attention problems: Parent rated: Ga: 62.64 ± 9.12 Gb: 67.67 ± 8.17 Ga/Gb: P < 0.05 Teacher rated: Ga: 59.36 ± 12.33 Gb: 63.25 ± 7.94 Ga/Gb: P = NS Aggression: Parent rated: Ga: 52.91 ± 4.98 Gb: 53.33 ± 4.62 Ga/Gb: P = NS Teacher rated: Ga: 57.60 ± 6.11 Gb: 61.25 ± 7.45 Ga/Gb: P < 0.01 Thought problems: Parent rated: Ga: 65.64 ± 9.87 Gb: 70.42 ± 7.92 Ga/Gb: P = NS Teacher rated: Ga: 65.55 ± 11.37 Gb: 72.58 ± 7.06 Ga/Gb: P < 0.05 Sensory: Personality Inventory for Children, parent rated, Internalizing/ somatic symptoms score, mean ± SD: Ga: 55.27 ± 13.90 Gb: 49.73 ± 8.77 Ga/Gb: P = NS Harms: NR Modifiers: NR

Comments:

* For all outcome measures, both treatment (G1 vs. G2) and time × treatment were not significant in the ANOVA.

Sofronoff et al., 2005

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Sofronoff et al., 2005 Country: Australia Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding Agency: NR Author industry relationship disclosures: NR Design: RCT | Intervention: Cognitive behavioral therapy: 6 week study (6 two-hour sessions); children were allocated in groups of 3 with 2 therapists in each group, within each treatment group by age and sex (girls grouped together) Sessions:; - Exploring positive emotions; - Exploration of anxiety and recognition of speech, thinking, physiological and behavior changes; - Exploration of social tools; - Measures of the degrees of emotion; - Exploring social stories; - Working together to design a program to improve the management of anxiety; In the child-only treatment, parents received no training but got instructtions for the weekly home-based projects; in the child and parents treatment, parents were trained to work as co-therapists and to complete home-based projects Assessments: Measures administered pre- and post-intervention and at 6 week follow-up: James and the Maths Test, SCAS-P, SWQ-P Groups: G1: child only G2: child and parents G3: wait-list group Provider: Therapists Measure of treatment fidelity reported: Yes | Inclusion criteria:; - Primary diagnosis of Asperger syndrome from a pediatrician; - Phone interview with a parent to establish DSM-IV criteria; - CAST score > 15; Exclusion criteria:; - See inclusion criteria; Age, mean/yrs ±SD: G1: 10.56 ± 0.99 G2: 10.54 ± 1.26 G3: 10.75 ± 1.04 Mental age: IQ, mean ± SD (range): G1: 107.5 ± 27.3 (90–137) G2: 105.6 ± 21.2 (90–135) G3: 101 ± 27.2 (95–125) Gender, n (%): Male: G1: 20 (87) G2: 22 (88) G3: 20 (87) Female: G1: 3 (13) G2: 3 (12) G3: 3 (13) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: DSM-IV checklist/CAST Diagnostic category, n (%): Autism: 0 PDD-NOS: 0 Aspergers: 71 (100) Other characteristics: Children’s depression inventory, mean ± SD: G1: 11.5 (8.27) G2: 10.25 (7.82) G3: 8.62 (5.80) | Commonly occurring comorbidities: SCAS-P score, mean ± SD: Total: G1: 40.23 ± 20.42 G2: 35.25 ± 16.44 G3: 36.64 ± 16.67 Separation anxiety: G1: 7.01 ± 4.46 G2: 6.79 ± 4.71 G3: 8.18 ± 4.45 OCD: G1: 5.11 ± 4.65 G2: 5.21 ± 3.67 G3: 4.96 ± 4.08 Social phobia: G1: 9.03 ± 4.45 G2: 7.93 ± 5.03 G3: 7.21 ± 4.75 Panic: G1: 4.88 ± 4.67 G2: 3.89 ± 2.84 G3: 4.18 ± 4.28 Personal injury: G1: 5.69 ± 3.37 G2: 5.07 ± 2.97 G3: 5.54 ± 3.28 GAD: G1: 8.42 ± 3.41 G2: 6.36 ± 3.30 G3: 6.57 ± 3.65 SWQ-P score, mean: G1: NR^*^ G2: NR^*^ G3: NR^*^ James and the Maths test score, mean: G1: NR^*^ G2: NR^*^ G3: NR^*^ | Commonly occurring comorbidities: SCAS-P score, 6 week follow-up, mean ± SD: Total: G1: 29.42 ± 15.3 G2: 21.11 ± 10.1 G3: 36.32 ± 13.3 G1/BL: P < 0.01 G2/BL: P < 0.01 G3/BL: P = NS G1/G2: P < 0.025 ANOVA: time (P < 0.0001), time × treatment (P < 0.0001) Separation anxiety: G1: 5.38 ± 3.7 G2: 3.03 ± 2.2 G3: 8.89 ± 4.5 G1/BL: P < 0.01 G2/BL: P < 0.0001 G3/BL: P = NS G1/G2: P < 0.02 G1/G3: P < 0.02 G2/G3: P < 0.001 ANOVA: treatment (P < 0.01), time (P < 0.0001), time × treatment (P < 0.0001) OCD: G1: 2.88 ± 2.9 G2: 2.21 ± 1.9 G3: 5.71 ± 4.4 G1/BL: P < 0.0001 G2/BL: P < 0.0001 G3/BL: P = NS ANOVA: time (P < 0.05), time × treatment (P < 0.05) Social phobia: G1: 7.38 ± 4.43 G2: 5.96 ± 4.32 G3: 6.61 ± 4.49 G1/BL: P < 0.05 G2/BL: P < 0.01 G3/BL: P = NS ANOVA: time (P < 0.05), time × treatment (P < 0.05)
| Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 23 G2: 25 G3: 23 N at follow-up: G1: 22 G2: 24 G3: 20 | Spence Child Anxiety Scale total score, mean ± SD: G1: 29.29 (17.45) G2: 32.23 (17.71) G3: 27.46 (12.19) Spence Child Anxiety Scale score, parent-rated, mean: Total score: 37.30 Panic/Agorophobia: 4.30 OCD: 5.10 Social phobia: 8.03 Physical injury: 5.43 Separation anxiety: 7.35 GAD: 7.09 | | Panic: G1: 3.31 ± 3.5 G2: 2.68 ± 2.4 G3: 3.35 ± 2.7 G1/BL: P < 0.01 G2/BL: P < 0.05 G3/BL: P = NS Personal injury: G1: 5.00 ± 3.9 G2: 3.32 ± 2.2 G3: 5.17 ± 3.8 G1/BL: P = NS G2/BL: P < 0.0001 G3/BL: P = NS GAD: G1: 5.46 ± 2.67 G2: 3.89 ± 2.36 G3: 6.57 ± 3.56 G1/BL: P < 0.0001 G2/BL: P < 0.0001 G3/BL: P = NS ANOVA: time (P < 0.05), time × treatment (P < 0.05) SWQ-P score, 6 week follow-up, mean: G1: NR^*^ G2: NR^*^ G3: NR^*^ G1/BL: P < 0.001 G2/BL: P < 0.0001 G3/BL: P = NS G1/G2: P = 0.06 G1/G3: P < 0.01 G2/G3: P < 0.0001 ANOVA: time (P < 0.0001), time × treatment (P < 0.0001)
| | | | James and the Maths test score, 6 week follow-up, mean: G1: NR^*^ G2: NR^*^ G3: NR^*^ G1/BL: P < 0.0001 G2/BL: P < 0.0001 G3/BL: P = NS G1/G2: P < 0.001 G1/G3: P < 0.001 G2/G3: P < 0.001 ANOVA: treatment (P < 0.0001), time (P < 0.0001), time × treatment (P < 0.0001) Harms: NR Modifiers: Parent involvement in comparison of interventions associated with less SCAS-P symptoms.

Comments:

* data only illustrated graphically

## 2004

Akhondzadeh et al., 2004

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Akhondzadeh et al., 2004 Country: Iran Practice setting: Academic Intervention setting: Clinic Enrollment period: January 2002 to January 2003 Funding: NR Author industry relationship disclosures: NR Design: RCT, double-blind placebo controlled | Intervention: Cyproheptadine titrated up to 0.05 mg/kg/day plus haloperidol titrated up to 0.2 mg/kg/day All patients received biperiden at 0.04 mg/kg/day as a prophylaxis against extrapyramidal symptoms Duration: 8 weeks Assessments: ABC-C, CARS, extra-pyramidal symptoms all assessed by third year psychiatry resident at baseline, 2, 4, 6 and 8 weeks after the start of medication Groups: G1: cyproheptadine plus haloperidol G2: placebo plus haloperidol Co-interventions held stable during treatment: NR Frequency of contact during study: Baseline and every two weeks Concomitant therapies: NR N at enrollment: G1: 20 G2: 20 N at follow-up: G1: 20 G2: 20 | Inclusion criteria:; - Ages 3–11 years; - DSM-IV clinical diagnosis of autism, confirmed by two child psychiatrists; - Outpatients from a specialty clinic for children at Roozbeh Psychiatric Teaching Hospital; - Chief complaint of severely disruptive symptoms related to autistic disorder; Exclusion criteria:; - Previously received neuroleptics; - Receiving any psychotropic drug treatment 6 months prior to recruitment; - Significant active medical problem; Age, years (SE) (range): G1: 6.40 (0.48) (3–11) G2: 6.90 (0.42) (3–11) Mental age: NR Gender, n (%): Male: G1: 13 (65) G2: 11 (55) Female: G1: 7 (35) G2: 9 (45) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In-study Diagnostic tool/method: DSM-IV Diagnostic category, n (%): Autism: 40 (100) | Overall ratings: CARS score, mean: G1: NR^*^ G2: NR^*^ G1/G2: P = 0.76 Problem behavior: ABC-C score, mean: G1: NR^*^ G2: NR^*^ G1/G2: P = 0.42 | Overall ratings: CARS score, week 8, mean change ± SD: G1: −1.85 ± 2.08 G2: −0.37 ± 0.48 G1+G2/BL: P = 0.003 G1/G2: P = 0.004 ANOVA: time (P < 0.0001), treatment (P = 0.045), time × treatment (P = 0.004) Problem behavior: ABC-C score, week 8, mean change ± SD: G1: 10.90 ± 7.19 G2: 3.70 ± 7.16 G1+G2/BL: P = 0.003 G1/G2: P = 0.006 ANOVA: time (P < 0.0001), treatment (P = 0.048), time × treatment (P = 0.002) Harms: Extrapyramidal symptoms: G1: 2 G2: 6 G1/G2: P = 0.23 Side effects, n:^**^ Trouble swallowing: G1: 2 G2: 4 Stiffness: G1: 1 G2: 3 Constipation: G1: 4 G2: 2 Diarrhea: G1: 2 G2: 3 Daytime drowsiness: G1: 1 G2: 2
| | Other characteristics: Weight, kg (SE): G1: 24.35 (1.29) G2: 25.00 (1.49) | | Slow movement: G1: 1 G2: 3 Restlessness: G1: 1 G2: 4 Morning drowsiness: G1: 3 G2: 2 Increased appetite: G1: 9 G2: 4 Fatigue: G1: 3 G2: 2 Modifiers: NR

Comments:

* Data only illustrated graphically.

** The between group difference was not significant for any side effects.

Aldred et al., 2004

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Aldred et al., 2004 Country: UK Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: Shirley foundation Author industry relationship disclosures: NR Design: RCT Note: See Aldred, Pollard, Phillips, and Adams, 2001 (not included in this report) for description of intervention | Intervention: Social communication intervention aiming to increase the quality of parental adaptation and communication with children with autism; monthly treatment sessions for 6 months followed by 6 months of less frequent maintenance sessions Assessments: ADI at baseline; ADOS modules 1 and 2 at baseline and post treatment; VABS, MCDI and PSI (parent completed), coding of 30-minute child/parent free play session with standardized toys to record frequency of communication acts (child and parent), semantic contingency, shared attention; conducted at baseline and end of 12 month follow-up Groups: G1: intervention and routine care G2: control (routine care only) Ga: aged 24–27 months, total ADOS score 11–17 (young high functioning) Gb: aged 24–47 months; total ADOS score 18–24 (young low functioning) Gc: aged 48–71 months; total ADOS score 11–17 (older high functioning) Gd: aged 48–71 months; total ADOS score 18–24 (older low functioning) Provider: Parent training by therapist Measure of treatment fidelity reported: No | Inclusion criteria:; - Ages 2–5:11 years; - Clinical diagnosis of autism by assessing professional; - Fulfilling full diagnostic for classical autism on the ADI; Exclusion criteria:; - Severe global developmental delay; - Severe environmental deprivation in infancy; - First language other than English; - Diagnosed hearing impairment; - Diagnosed visual impairment; - Known chronic psychiatric or physical illness in parents; - No evidence of any desire to interact with an adult; Age, median months (range): G1: 48 (29–60) G1a: 37.5 (29–45) G1b: 44 (38–44) G1c: 61 (51–70) G1d: 60 (53–60 G2: 51 (24–71) G2a: 42 (32–47) G2b: 33 (24–40) G2c: 64 (54–71) G2d: 67 (54–71) Mental age: NR Gender, n (%): Male: G1: 13 (93) G1a: 4 (100) G1b: 3 (100) G1c: 4 (100) G1d: 3 (75) G2: 12 (86) G2a: 4 (100) G2b: 2 (66) G2c: 3 (100) G2d: 3 (75) | Overall ratings: ADI score, median (range): G1: 44 (24–56) G1a: 45 (24–56) G1b: 40 (30–48) G1c: 53 (50–56) G1d: 38 (34–38) G2: 38 (22–66) G2a: 34 (22–62) G2b: 36 (28–39) G2c: 38 (22–66) G2d: 52 (28–54) ADOS total score, median (range): G1: 16.5 (11–21) G1a: 12.5 (11–16) G1b: 20 (18–20) G1c: 16 (11–17) G1d: 21 (19–21) G2: 16.5 (11–22) G2a: 13 (11–15) G2b: 19 (19–21) G2c: 16 (11–16) G2d: 20 (18–22) ADOS total score, mean ± SD: G1: 16.1 ± 4.5 G1a: 12 ± 3.3 G1b: 19 ± 1.3 G1c: 14 ± 3.3 G1d: 20 ± 1 G2: 15.6 ± 4.9 G2a: 11 ± 2.3 G2b: 19 ± 1 G2c: 14 ± 3.3 G2d: 20 ± 1.3 Communication/language: MCDI, raw score, mean ± SD: Language comprehension: G1: 71.7 ± 2383^*^ G2: 95.4 ± 426^*^ Expressive language: G1: 28 ± 467^*^ G2: 25.6 ± 683^*^ Adaptive behavior: VABS communication, mean ± SD: G1: 22.6 ± 13.3 G2: 20.0 ± 10.8 | Overall ratings: ADOS total score: mean ± SD: G1: 11.8 ± 6.4 G1a: 6 ± 3.6 G1b: 13 ± 5.6 G1c: 11 ± 4.5 G1d: 17 ± 2.6 G2: 16.1 ± 4.4 G2a: 13 ± 4 G2b: 16 ± 4.3 G2c: 16 ± 1.3 G2d: 20 ± 0.6 Communication/language: MCDI raw score, mean ± SD: Language comprehension: G1: 222.7 ± 40,431^*^ G2: 146.8 ± 11,426^*^ G1/G2: P = 0.1 Expressive language: G1: 199.4 ± 25,606^*^ G2: 33.1 ± 683^*^ G1/G2: P < 0.001 Adaptive behavior: VABS communication score, mean ± SD: G1: 36.9 ± 21.2 G2: 28.7 ± 16.6 G1/G2: P = NS Parent-child interaction codes, mean frequency ± SD: Parent synchrony: G1: 65.1 ± 14.3 G2: 49.5 ± 18.9 G1/G2: P = 0.016 Parent asynchrony: G1: 32.6 ± 14.3 G2: 50.5 ± 18.8 G1/G2: P = 0.009
| Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 14 G1a: 4 G1b: 3 G1c: 4 G1d: 3 G2: 14 G2a: 4 G2b: 3 G2c: 4 G2d: 3 N at follow-up: G1: 14 G1a: 4 G1b: 3 G1c: 4 G1d: 3 G2: 14 G2a: 4 G2b: 3 G2c: 4 G2d: 3 | Female: G1: 1 (7) G1a: 0 G1b: 0 G1c: 0 G1d: 1 (25) G2: 2 (14) G2a: 0 G2b: 1 (33) G2c: 0 G2d: 1 (25) Race/ethnicity, mothers, n: African-Caribbean: 2 Caucasian: 26 SES: Maternal education, median years (range): 16.5 (16–21) Paternal education, median years (range): 17.6 (16–21) Household income: NR Diagnostic approach: Clinician/self referral and in study Diagnostic tool/method: ADI Diagnostic category, n (%): Autism: 28 (100) Other characteristics: NR | Parent-child interaction codes, mean frequency ± SD: Parent synchrony: G1: 57.8 ± 15 G2: 57.1 ± 49.5 Parent asynchrony: G1: 39.7 ± 16.1 G2: 42.9 ± 16.1 Child communication acts: G1: 30.8 ± 10.2 G2: 30.1 ± 11.1 Parent communication acts: G1: 66.3 ± 11.8 G2: 70.7 ± 11 Child shared attention: G1: 72 ± 23.6 G2: 62.8 ± 24.5 Parent shared attention G1: 93.5 ± 5.3 G2: 81.3 ± 22.3 | Child communication acts: G1: 37.6 ± 10.1 G2: 27.6 ± 16.5 G1/G2: P = 0.041 Parent communication acts: G1: 64.4 ± 13 G2: 72.4 ± 16.5 G1/G2: P = 0.293 Child shared attention: G1: 77.6 ± 17.8 G2: 62.6 ± 32.7 G1/G2: P = 0.204 Parent shared attention: G1: 88.6 ± 8.7 G2: 80.3 ± 30.1 G1/G2: P = 0.176 Harms: NR Modifiers: NR

Comments:

* Standard deviations (as reported in paper) appear to be in error.

Chez et al., 2004

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Chez et al., 2004 Country: US Practice setting: Specialty treatment center Intervention setting: Clinic Enrollment period: Month : NR Funding: NR Author industry relationship disclosures: NR Design: Prospective case series | Intervention: 12 week open-label study with Rivastigmine tartarate At BL, 0.2 ml (0.4 mg) of rivastigmine tartarate given twice daily in a liquid suspension (2mg.ml). If any adverse event, dosage was halved or discontinued. If no improvement after 2 wks of starting on the medicaton, dosage was doubled to 0.4 ml (0.8mg) twice daily Maximum daily dose was 0.4 ml (0.8mg) twice daily Assessments: Expressive One Word Vocabulary Test, Childhood Autism Rating Scale administered by study coordinator at baseline, 6wks and 12 wks. Conners’ Parent Rating Scale completed by parents at baseline, 6wks, 12 wks. Groups: G1: Rivastigmine tartarate Co-interventions held stable during treatment: NR Frequency of contact during study: Testing at Baseline, 6 weeks, 12 weeks. Nurses contacted parents weekly to check for any concerns. Concomitant therapies, n: Anticonvulsants: 21 CNS stimulants: 8 Adrenergic blockers: 4 Antipsychotics: 2 Antidepressants: 1 Corticosteroids: 1 N at enrollment: G1: 32 | Inclusion criteria: Based on diagnosis of ASD or PDD-NOS per DSM-IV Exclusion criteria: See inclusion criteria Age, mean/yrs (range): 6.91 (2.85–12) Mental age: NR Gender: M, n (%): 24 (75) F, n (%): 8 (25) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In Study/Referral Diagnostic tool/method: DSM-IV Diagnostic category, n (%): Autism: 11 (34.4) PDD-NOS : 21 (65.6) Other characteristics, n (%): Previous diagnosis of nocturnal epileptiform EEG abnormalities: 13 (40.6) | Overall ratings: CARS, mean ± SD: 34 ± 6.36 Communication/language: Expressive one-word Picture vocabulary test, mean ± SD: 34.91 ± 33.61 Receptive One-word Picture Vocabulary test, mean ± SD: 37.78 ± 29.70 Problem behavior: Conner’s parent rating scale, mean ± SD: 34.5 ± 12.30 | Changes from baseline to 12 weeks: Overall ratings: CARS, mean ± SD: 30.84 ± 8.71 P = 0.001 Communication/language: Expressive one-word Picture vocabulary test, mean ± SD: 41.44 ± 36.74 P = 0.001 Receptive One-word Picture Vocabulary test, mean ± SD: 39.53 ± 32.47 P = NS Problem behavior: Conner’s parent rating scale, mean ± SD: 28.28 ± 13.53 P = 0.005 Harms: NR Modifiers: NR
| N at follow-up: G1: 32

Dillenburger et al., 2004

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Dillenburger et al., 2004 Country: Ireland Practice setting: Academic Intervention setting: Home and academic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: Retrospective case series | Intervention: Applied Behavior Analysis (parents educated in general ABA principles for use at home with their children) Frequency: parent training every 2 weeks for 18 weeks; parents supposed to apply skills from course at home “as frequently as possible” throughout the day; weekly family visit from ABA professional to supervise and adjust Assessments: ABA evaluation questionnaires were completed by families (post-intervention only) Possible responses for difference:; - Great difference; - Some difference; - Little difference; - Don’t Know; - Not applicable; Possible responses for effectiveness:; - Very effective; - Effective; - Not effective; - Don’t know; - Not applicable; Groups: G1: long term group (≥ 18 months of ABA) G2: short term group (≤ 12 months of ABA) Provider: ABA professionals Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR | Inclusion criteria:; - Actively engaged in home-based ABA program at time of study; - Children with ASD (diagnostic process/criteria not described); Exclusion criteria:; - See inclusion criteria; Age, months (range): Study entry: G1: 125 G2: 52 Start of ABA G1: 91 G2: 46 Age, study entry, range (years): Total: 3–13 Mental age: NR Gender, n (%): Male: G1: 10 (83.3) G2: 9 (90) Female: G1: 2 (16.7) G2: 1 (10) Race/ethnicity: NR SES:^*^ Maternal education: NR Parents employed, n: G1: 8 G2: 5 Diagnostic approach: NR Diagnostic tool/method: NR Diagnostic category: NR Other characteristics: Number of other children, mean (range): G1: 3 (1–4) G2: 2.5 (1–3) | NR | Overall ratings: Parent perceived difference from ABA on child behavior, n: Independence: Great difference: G1: 3/11 G2: 5/10 Some difference: G1: 8/11 G2: 4/10 No difference: G1: 0 G2: 1/10 Quality of life: Great difference: G1: 7/11 G2: 8/10 Some difference: G1: 2/11 G2: 2/10 Little difference: G1: 1/11 G2: 0 Don’t know: G1: 1/11 G2: 0 Skills development: Great difference: G1: 8/11 G2: 8/10 Some difference: G1: 3/11 G2: 2/10 Skills maintenance: Great difference: G1: 6/11 G2: 6/10 Some difference: G1: 5/11 G2: 4/10 Interaction: Great difference: G1: 6/11 G2: 7/10 Some difference: G1: 5/11 G2: 3/10
| N at enrollment: G1: 25 G2: 25 N at follow-up: G1: 12 G2: 10 | Length of involvement with ABA, months (range): G1: 35.5 (18–72) G2: 6.1 (2–12) | | Parent perceived effectiveness of ABA on child behavior, n: Self-help skills: Very effective: G1: 6/12 G2: 4/10 Effective: G1: 3/12 G2: 4/10 Not effective: G1: 2/12 G2: 0 Don’t know: G1: 1/12 G2: 2/10 Social skills: Very effective: G1: 9/12 G2: 4/10 Effective: G1: NR G2: 5/10 Not Effective: G1: 1/12 G2: 1/10 Problem behavior: Very effective: G1: 9/12 G2: 5/10 Effective: G1: 3/12 G2: 5/10 Obsessive behavior: Very effective: G1: 8/12 G2: 4/10 Effective: G1: 4/12 G2: 3/10 Not applicable: G1: 0 G2: 3/10 Gross motor skills: Very effective: G1: 9/12 G2: 6/10 Effective: G1: 3/12 G2: 3/10
| | | | Not applicable: G1: 0 G2: 1/10 Fine motor skills: Very effective: G1: 9/12 G2: 6/10 Effective: G1: 3/12 G2: 4/10 Communication: Very effective: G1: 9/12 G2: 7/10 Effective G1: 3/12 G2: 3/10 Concentration: Very effective: G1: 10/12 G2: 9/10 Effective: G1: 2/12 G2: 1/10 Harms: NR Modifiers: NR

Comments:

* G1 and G2 described as “equivalent” with regards to socioeconomic status; details NR.

Mukaddes et al., 2004

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Mukaddes et al., 2004 Country: Turkey Practice setting: Academic Intervention setting: clinic, home Enrollment period: 2000 to 2005 Funding: NR Author industry relationship disclosures: NR Design: Prospective case series | Intervention: Psychoeducational program developing reciprocal interaction, enhancing communication, modifying stereotypic behavior, and increasing self-care; focused on parent training using principles from TEACCH; 11–14 weekly 45-min sessions. First stage (sessions 1+2) parent education. 2^nd^ stage (10–12 sessions) child-directed play. Groups: G1: Autism Assessments: Ankara Development Screening Inventory at baseline and end of intervention Provider: Experienced child educators Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 10 N at follow-up: G1: 10 | Inclusion criteria: NR Exclusion criteria: NR Age, mean/months ± SD (range): G1: 43.2 ± 15.17 (24–66) Mental age: NR Gender: G1: M, n (%): 10 (100) F, n (%): 0 Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In study Diagnostic tool/method: Based on DSM-IV Diagnostic category: NR Other characteristics: NR | Overall ratings: Ankara Development Screening Inventory (ADSI), median total development score: G1: 16.5 Language-cognitive subscale: G1: 15.5 Social/self-care abilities subscale: G1: 16.5 Fine motor subscale: G1: 18.5 Gross motor subscale: G1: 49.0 | Overall ratings: ADSI, median total development score (p-values within group differences from baseline): G1: 22.5 P = 0.005 Language-cognitive subscale: G1: 20.0 P = 0.005 Social/self-care abilities subscale: G1: 26.75 P = 0.002 Fine motor subscale: G1: 26.75 P = 0.002 Gross motor subscale: G1: 51 P = 0.008 Harms: NR Modifiers: NR

Posey et al. 2004

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Posey et al. 2004 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: October 1997 to April 2001 Funding: National Alliance for Research in Schizophrenia and Depression, Daniel X. Freedman Psychiatric Fellowship, NIMH, and Department of Housing and Urban development Author industry relationship disclosures: NR Design: Retrospective case series | Intervention: Guanfacine (.25–9 mg daily in divided doses Mean daily dose: 2.6 ± 1.7 mg Mean duration of treatment: 334 ± 374 days, range 7–1776 days N=70 (age range, 3–11 years, mean daily dose = 2 mg) N=10 (age range, 13–18 years, mean daily dose= 3.4 mg) Dosing frequency: N=2 (once daily) N=48 (twice daily) N=29 (three times daily) N=1 (four times daily) Assessments: Conducted by 2 board-certified child and adolescent psychiatrists; CGI Groups: G1: Guanfacine Co-interventions held stable during treatment: NR Frequency of contact during study: NR Concomitant therapies, n (%): Overall: 44(55) Atypical antipsychotics: 16 (20%) SSRIs: 13 (16%) Stimulants: 9 (11%) Non-SSRI antidepressants: 8 (10%) Mood stabilizers: 8 (10%) Conventional antipsychotics: 3 (4%) N at enrollment: G1: 80 | Inclusion criteria:; - Treated at the Autism/PDD Clinic at the James Whitcomb Riley Hospital for Children; - Diagnosis of PDD by DSM-IV; - History of guanfacine treatment within the clinic; Exclusion criteria: See inclusion criteria Age, mean/yrs ± SD (range): G1: 7.7 ±3.5 (3–18) Mental age: NR Gender: G1: M, n (%): 70 (87) F, n (%): 10 (13) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In-study Diagnostic tool/method: DSM-IV criteria clinical Diagnostic category, n (%): G1: Autistic disorder: 46 (56) Asperger’s disorder: 6 (8) PDD-NOS: 28 (35) | Overall ratings: CGI severity, mean ± SD: Inattention: 4.58 ± 0.68 Hyperactivity: 4.75 ± 0.9 Impulsivity: 4.61 ± 0.73 Aggression/self-injury: 4.54 ± 0.95 Anxiety/worry: 4 ± 0.59 Irritability: 4.65 ± 0.66 Insomnia: 4.04 ± 0.82 Repetitive behaviors: 3.67 ± 0.78 Tics: 3.83 ± 0.75 Social impairment: 4.05 ± 0.87 Language: 4.23 ± 1.04 Overall: 4.83 ±0.71 Medical: mean ± SD: SBP:109.6 ± 13.8 DBP: 65.7 ± 10.9 Heart rate: 95.7 ± 15.8 | Overall ratings: CGI, n (%): 19 (23.8) subjects considered responders based on “much improved” or “very much improved” CGI global improvement item CGI Global Improvement score, mean ± SD: Responders: 1.9 ± 0.2 Non-responders: 3.6 ± 0.6 Improvement in CGI Severity score, mean ± SD: 4.25 ± 0.91 T = 6.5 (P < 0.0001) CGI severity, mean ± SD (%)improvement, n/N subjects showing improvement: Inattention: 3.91 ± 0.87 (21.10), 16/76 Hyperactivity: 3.92 ± 1.05 (26.7), 20/75 Impulsivity: 4.07 ± 0.9 (17.4), 12/69 Aggression/self-injury: 4.13 ± 1.03 (14.5), 10/69 Anxiety/worry: 3.64 ± 0.72 (11.1), 4/36 Irritability: 4.06 ± 0.92 (16.9), 13/77 Insomnia: 3.22 ± 0.99 (27.5), 14/51 Repetitive behaviors: 3.59 ± 0.74 (0), 0/54 Tics: 2.33 ± 0.82 (50), 3/6
| N at follow-up: G1: 80 | Other characteristics, n (%): Comorbid mental retardation: 56 (70); - Mild: 25 (31.25); - Moderate: 25 (31.25); - Severe: 6 (7.5); Seizure disorders: 11 (14) | | Social impairment: 3.97 ± 0.82 (0), 0/78 Language: 4.05 ± 1.01 Communication impairment, % improvement, n/N: 3.1, 2/65 Medical, mean ± SD: SBP: 107.6 ± 16.1 DBP: 64.3 ± 10.6 Heart rate: 94.6 ± 16.6 No difference in BPs or heart rate following treatment with guanfacine Harms, n (%): Transient sedation: 25 (31) Irritability: 5 (6) Constipation: 3 (4) Headache: 2 (3) Nocturnal Enuresis: 2 (3) Modifiers: PDD-NOS (39.3% responders) and Asperger’s (33.3% responders) had greater rate of global response than those with autistic disorder (13.0% responders) (P = 0.009) Responders had history of significantly fewer psychotropic drug trials than non-responders (1.3 ± 1.6 vs. 3.0 ± 3.4, P = 0.046).
| | | | Responders were less aggressive at baseline by CGI severity item (P = 0.04).

Sofronoff et al., 2004

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Sofronoff et al., 2004 Country: Australia Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: RCT Note: See related paper with overlapping participants, Sofronoff et al., 2004 ({#1039}) | Intervention: Parent Management Training (PMT), in the form of a 1-day workshop or six weekly individual sessions. Both groups followed a manual with six components (1 hour each), including: psycho-education, comic strip conversations (Gray, 1994a), social stories (Gray, 1994b), management of behavior problems, management of rigid behaviors, routines, and special interests, and anxiety management. Groups: G1: workshop G2: individual G3: wait-list Provider: Clinical master’s or PhD students completing an internship at the Behavior Research and Therapy Center (University of Queensland) Assessment: ECBI, Child’s Social Skills questionnaire at baseline, 4 weeks and 3 month follow-up Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 18 G2: 18 G3: 15 N at follow-up: G1: 18 G2: 18 G3: 15 | Inclusion criteria: NR Exclusion criteria: NR Age, years (range): G1: 9.33 (6–12) Gender: NR Race/ethnicity: NR SES: NR Diagnostic approach: In Study Diagnostic tool/method: By pediatrician at clinic site Diagnostic category, n (%): Asperger: 51 (100) Other characteristics: NR | Problem behavior: ECBI, number of problem behaviors, mean ± SD: G1: 17.44 ± 5.77 G2: 16.89 ± 5.84 G3: 18.13 ± 5.19 ECBI, intensity of problem behaviors, mean ± SD: G1: 149.72 ± 29.78 G2: 140.44 ± 22.59 G3: 144.73 ± 26.39 Social Skills: Social skills questionnaire score, mean ± SD: G1: 23.66 ± 8.92 G2: 25.22 ± 10.01 G3: 25.07 ± 6.64 | Problem behavior: ECBI, number of problem behaviors, 3 months, mean ± SD: G1: 12.50 ± 6.96 G2: 8.67 ± 4.93 G3: 18.20 ± 6.21 G1/BL: P < 0.005 G2/BL: P < 0.0001 G3/BL: P = NS G1/G2: P = NS G1/G3: P < 0.01 G2/G3: P < 0.0001 MANOVA: time (P < 0.0001), treatment (P < 0.005), time × treatment (P < 0.001) ECBI, intensity of problem behaviors, 3 months, mean ± SD: G1: 129 ± 18.13 G2: 106.44 ± 22.99 G3: 144.40 ± 31.85 G1/BL: P < 0.0001 G2/BL: P < 0.0001 G3/BL: P = NS G1/G2: P < 0.01 G1/G3: P = NS G2/G3: P < 0.0001 MANOVA: time (P < 0.0001), treatment (P < 0.01), time × treatment (P < 0.001)
| | | | Social Skills: Social skills questionnaire score, 3 months, mean ± SD: G1: 31 ± 9.01 G2: 36.61 ± 8.24 G3: 24.27 ± 8.57 G1/BL: P < 0.0001 G2/BL: P < 0.0001 G3/BL: P = NS G1/G2: P = 0.057 G1/G3: P < 0.05 G2/G3: P < 0.0001 MANOVA: time (P < 0.0001), treatment (P < 0.05), time × treatment (P < 0.001) Harms: NR Modifiers: NR

Solomon et al., 2004

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Solomon et al., 2004 Country: US Practice setting: Academic, medical center Intervention setting: Clinic Enrollment period: NR Funding: UC Davis MIND Institute, UC Davis Health System, UC Davis Author industry relationship disclosures: NR Design: RCT, age and IQ matched intervention and waiting list control | Intervention:; - Social adjustment enhancement curriculum targeting social skills in a group setting with standardized agenda including welcome song, review of previous lessons, conversational and motor activity skills interventions; - Curriculum focused on teaching skills in emotion/facial expression recognition in self and others, theory of mind, executive functions with emphasis on problem solving, and conversational skills; - Parent training component with focus on enhancing parental understanding of child’s social problems; - Weekly problem behavior logs completed by parents to facilitate child social behavior management; Assessments: DANVA, Theory of Mind, Faux Pas Stories, Test of Problem Solving, conducted in clinic by examiner; Children’s Depression Inventory, Beck Depression Inventory competed by child with mother present in clinic; parent-completed weekly social behavior problem logs Duration: 20 weeks Frequency: weekly, 1.5 hours/week | Inclusion criteria:; - Ages 8–12 years; - Prior diagnosis of High Functioning Autism (HFA), Asperger Syndrome (AS) or Pervasive Developmental Disorder NOS (PDDNOS) confirmed by ADOS-G and ADI-R and DSM-IV criteria for HFA, PDDNOS or AS based on clinical interview; - Full Scale IQ score from within past 2 years ≥ 75 as measured by WISC-III or WASI; - Demonstrated ability to pass Smarties false belief task; Exclusion criteria:; - Serious conduct problems; Age, months (range): G1a: 103 (93–117) G1b: 130 (111–146) G2a: 100 (88–117) G2b: 122 (108–140) Mental age: VIQ, mean (range): G1a: 126 (117–136) G1b: 86 (75–94) G2a: 121 (92–142) G2b: 82 (59–91) PIQ, mean (range): G1a: 103 (89–112) G1b: 88 (63–115) G2a: 114 (85–136) G2b: 108 (90–122) FSIQ, mean (range): G1a: 115 (99–124) G1b: 86 (75–100) G2a: 119 (88–143) G2b: 95 (83–104) Gender, n (%): Male: 18 (100) Female: 0 (0) Race/ethnicity: NR SES: Maternal education: NR Household income: NR | Communication/language: DANVA score, mean ± SD (range): Adult faces: G1a: 12.2 ± 1.1 (11–14) G1b: 10.5 ± 1.3 (9–12) G2a: 11.8 ± 2.2 (10–15) G2b: 12.4 ± 1.3 (11–14) Child faces: G1a: 11.6 ± 1.5 (10–14) G1b: 12.0 ± 2.4 (10–15) G2a: 13.0 ± 1.2 (12–15) G2b: 12.8 ± 0.9 (12–14) Total faces: G1a: 23.8 ± 1.3 (23–26) G1b: 22.5 ± 2.9 (19–26) G2a: 24.8 ± 3.1 (22–30) G2b: 25.2 ± 2.2 (23–28) Theory of Mind score, mean ± SD (range): Strange stories: G1a: 10 ± 1 (9–11) G1b: 6.5 ± 1.7 (7–11) G2a: 9.2 ± 1.6 (4–8) G2b: 7.4 ± 1.3 (6–9) Faux pas: G1a: 2.6 ± 2.1 (0–5) G1b: 0.75 ± 0.5 (1–4) G2a: 2.8 ± 1.3 (0–1) G2b: 1.2 ± 0.5 (1–2) | Communication/language: DANVA score, mean ± SD (range): Adult faces: G1a: 13.4 ± 1.1 (12–15) G1b: 12.8 ± 2.9 (9–15) G2a: 11.2 ± 1.3 (10–13) G2b: 11.8 ± 2.4 (10–15) G1/BL: P < 0.05 G1/G2: P < 0.05 Ga/Gb: P = NS Child faces: G1a: 13.2 ± 1.8 (11–16) G1b: 12.0 ± 1.8 (10–14) G2a: 12.8 ± 1.5 (11–15) G2b: 11.8 ± 2.1 (9–14) G1/BL: P < 0.05 G1/G2: P < 0.05 Ga/Gb: P = 0.05 Total faces: G1a: 26.6 ± 1.5 (25–29) G1b: 24.8 ± 3.4 (20–28) G2a: 24.0 ± 2.3 (22–28) G2b: 23.6 ± 3.3 (19–27) Theory of Mind score, mean ± SD (range): Strange stories: G1a: 10.4 ± 0.9 (9–11) G1b: 7.3 ± 0.5 (7–11) G2a: 9.4 ± 1.8 (7–8) G2b: 7.5 ± 1.3 (6–9) G1-2/BL: P = NS G1/G2: P = NS
| Provider: Social skills group leaders consisting of psychologists, a psychiatrist, a speech and language pathologist; providers working with parents were a developmental and behavioral pediatrician and a social worker Groups: G1: received curriculum G2: randomized to wait list for later participation in curriculum (controls) Ga: younger participants with higher mean FSIQ Gb: older participants with lower mean FSIQ Treatment manual followed: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 9 G1a: 5 G1b: 4 G2: 9 G2a: 5 G2b: 4 N at follow-up: G1: 9 G1a: 5 G1b: 4 G2: 9 G2a: 5 G2b: 4 | Diagnostic approach: In study Diagnostic tool/method: ADOS-G and ADI-R and DSM-IV criteria for HFA, PDDNOS or AS based on clinical interview Diagnostic category, N: G1a: Asperger’s Syndrome:3 High-Functioning Autism:1 PDD-NOS:1 G1b: Asperger’s Syndrome:2 High-Functioning Autism:2 G2a: Asperger’s Syndrome:5 G2b: Asperger’s Syndrome:2 High-Functioning Autism:2 Other characteristics: ADOS mean (range): G1a: 9 (97–14) G1b: 15 (12–18) G2a: 9 (7–13) G2b: 14 (11–17) | TOPS elementary-revised, percentile rank score, mean ± SD (range): G1a: 32.2 ± 13.9 (13–44) G1b: 2.25 ± 1.5 (1–4) G2a: 41.6 ± 30 (2–73) G2b: 2.75 ± 0.5 (2–3) Children’s Depression Inventory score, mean ± SD (range): G1a: 6.0 ± 1.6 (4–8) G1b: 6.25 ± 4.3 (2–12) Beck Depression Inventory score, mothers, mean ± SD (range): G1: 5.9 ± 7.2 (0–20) Problem Behavior Logs, first 8 weeks, mean: Problem behavior reports per time: 9.6 Parent satisfaction with their handling of children’s problem behavior: 6.2/10 | Faux pas: G1a: 5.4 ± 0.9 (4–6) G1b: 3.0 ± 2.2 (1–6) G2a: 3.6 ± 2.5 (0–5) G2b: 3.0 ± 1.2 (2–4) G1-2/BL: P < 0.001 G1/G2: P = NS TOPS elementary-revised, percentile rank score, mean ± SD (range): G1a: 43.2 ± 22 (10–65) G1b: 1.5 ± 1 (1–3) G2a: 23.8 ± 13 (6–42) G2b: 2.0 ± 1.2 (1–3) G1/BL: P < 0.05 G1/G2: P < 0.05 Children’s Depression Inventory score, mean ± SD (range): G1a: 8.4 ± 5.0 (4–17) G1b: 3.8 ± 3.2 (1–7) G1a/G1b: P < 0.05 Beck Depression Inventory score, mothers, mean ± SD (range): G1: 3.89 ± 3.3 (0–9) G1/BL: P = NS
| | | | Problem Behavior Logs, first 8 weeks, mean: Problem behavior reports per time: 5.9 (P < 0.05) Parent satisfaction with their handling of children’s problem behavior: 6.9/10 (P = 0.11) Harms: NR Modifiers: Theory of Mind: significant correlation with VIQ (P < 0.001) & FSIQ (P < 0.05) TOPS: significant correlation with VIQ (P < 0.001) & FSIQ (P < 0.05) Average problem behavior log satisfaction with handling problem behaviors was correlated (P < 0.10) with mother’s depression score but not statistically significant

Comments:

* “all four children who engaged in combinations with their augmentative system also used single spoken language for the communication; as a result, these four children are reported in both categories”(p.79)

Stahmer & Ingersoll, 2009

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Stahmer & Ingersoll, 2009 Country: US Practice setting: Academic Intervention setting: Classroom Enrollment period: NR Funding: Children’s Hospital Research grant NIH California Early Start Author industry relationship disclosures: NR Design: Case series, prospective | Intervention: Children’s Toddler School (CTS),; - inclusive classroom serving 8 children with ASD and 8 typically developing children (4 in the morning, 4 in the afternoon), inclusion sessions 3 hours a day, 5 days a week,; - special skills training: 30 min/4 days a week of one-to-one teaching; - arranged like typical toddler classroom (i.e. toys for appropriate levels of paly); - Family participation component: weekly 2 hour home visit, home teacher and psychologist accompany family through transition; Assessments: Administered at entry and approx. 1 week before child completed treatment: BSID-II (by program psychologist), VABS (by program director to parent), GARS (parent questionnaire), and checklist of functional skills developed by authors (by program psychologist). Mean age at exit: 35 mo. Groups: G1: Children’s Toddler School (CTS) Provider:; - Special and early education classroom teachers, at least bachelor’s degree; - Speech therapist/occupational therapist | Inclusion criteria:; - participated in CTS program for a minimum of 6 months; - received from a clinician not associated with the project an independent diagnosis of ASD; - minimum nonverbal mental age of 12 mo. (on BSID-II); - less than 2 years 6 mo. of age; Exclusion criteria: See above Age, mean/months (range): 27.6 (22–31) Mental age, BSID-II mean ± SD: G1: 67.2 ± 14.7 (n=19) Gender: n (%): M, 16 (80%) F, 4 (20%) Race/ethnicity, n (%): White: 12(60) Asian: 2 (10) Hispanic: 4(20) Filipino: 2(10) SES: Maternal education: NR Household income: NR Four Factor Index of Social Status, n (%): Major business/professional: 5( 25) Med. business/minor professional: 10(50) Skilled workers: 2(10) Semiskilled workers: 3(15) Unskilled laborers: 0(0) Diagnostic approach: Referral Diagnostic tool/method: DSM-IV | Overall ratings: VABS, n, mean age equivalent: G1: 16, 14 GARS, n, mean ± SD: G1: 19, 87.2 ± 11.2 Social skills: VABS Socialization, n, mean ± SD: G1: 16, 70.4 ± 8.9 VABS socialization range of functioning, n (%): Typical range 1 (6) Reported functional social interaction skills, n (%): Avoidant: 8 (40) Facilitated: 8 (40) Parallel play: 4 (20) Responsive to peers: 0 (0) Reciprocal play: 0 (0) Communication/language: VABS Communication, n, mean ± SD: G1: 16, 71.1 ± 13.9 VABS communication range of functioning, n (%): Severely delayed range: 1 (6) Mildly delayed range: 7 (44) Borderline range: 7 (44) Average range: 1 (6) Reported functional communication skills, %: No functional communication system: 50 | Overall ratings: VABS, n, mean age equivalent: G1: 16, 21 GARS, n, mean ± SD: G1: 19, 76.5 ± 23.0 P < 0.05 Social skills: VABS Socialization, n, mean ± SD: G1: 16, 75.0 ± 10.9 P < 0.05 VABS socialization range of functioning, n (%): Typical range: 5 (31) Reported functional social interaction skills, n (%): Avoidant: 0 (0) Facilitated: 3 (15) Parallel play: 5 (25) Responsive to peers: 5 (25) Reciprocal play: 7 (35) P < 0.01 Communication/language: VABS Communication, n, mean ± SD: G1: 16, 79.3 ± 17.1 P < 0.01 44% of children showed increases VABS communication range of functioning, n (%):
| Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies, n (%): Gluten/casein-free diets: 4 (20) Individual occupational therapy: 2 (10) Individual speech therapy: 1 (5) 10 hours a week of discrete trial training: 1 (5) 3 hours a week of naturalistic intervention: 1 (5) N at enrollment: G1: 20 N at follow-up: G1: 20 | Diagnosis confirmed in study using standardized assessments including: CARS GARS Diagnostic category, %: Autism: 55 PDD-NOS: 45 Other characteristics: NR | Single signs or PECS: 0 Combinations with augmentative system: 0 Single spoken words: 35 Phrases: 15 Commenting/sharing: 0 Adaptive behavior: VABS Daily Living Skills, mean ± SD: G1: 16, 71.2 ± 8.9 Reported functional play skills, n (%): No functional play: 7 (35) Cause/effect play: 3 (15) Relational play: 7 (35) Simple pretend play: 3 (15) Complex pretend play: 0 (0) Motor skills: VABS Motor Skills, n, mean ± SD: G1: 16, 88.9 ± 12.5 Educational/cognitive/academic attainment: BSID-II, n, mean ± SD: G1: 19, 67.2 ± 14.7 IQ score (BSID-II), n (%): G1: below 70 (significantly delayed range): 11 (58) 70–84 (mildly delayed range): 6 (32) 85–115 (normally developing range): 2 (11) | Severely delayed range: 0 (0) Mildly delayed range: 6 (38) Borderline range: 5 (31) Average range: 5 (31) 4 of 15 (27) moved to normal range Reported functional communication skills, n (%): No functional communication system: 2 (10) Single signs or PECS: 2 (10) Combinations with augmentative system: 4 (20)^*^ Single spoken words: 4 (20)^*^ Phrases: 3 (15) Commenting/sharing: 9 (45) P < 0.01 Adaptive behavior: VABS Daily Living Skills, n, mean ± SD: G1: 16, 72.8 ± 9.4 P = NS Reported functional play skills, n (%): No functional play: 0 (0) Cause/effect play: 0 (0) Relational play: 7 (35) Simple pretend play: 5 (25) Complex pretend play: 8 (40) P<.01
| | | BSID-II nonverbal mental age, mean, rate of development (as compared to typical children): G1: 18, 64 BSID-II verbal mental age, rate of development (as compared to typical children): G1: 53 | Motor skills: VABS Motor Skills, n, mean ± SD: G1: 16, 87.4 ± 16.1 P = NS Educational/cognitive/academic attainment: BSID-II, n, mean ± SD: G1: 19, 74.6 ± 17.9 P < 0.01 developmental quotient increased in 47% of children IQ score (BSID-II), n (%): G1: Below 70 (significantly delayed range): 8 (42) 70 – 84 (mildly delayed range): 4 (21) 85 – 115 (normally developing range): 7 (37) 67% of children in mildly delayed range increased to normal range 5% (1 child) increased from significantly delayed range to normal range BSID-II nonverbal mental age, mean, rate of development (as compared to typical children): G1: 26, 74
| | | | BSID-II nonverbal mental age developmental trajectory: G1: (graph) 10% increase in developmental progress BSID-II verbal mental age, rate of development (as compared to typical children): G1: 67 BSID-II verbal mental age developmental trajectory: G1: (graph) 14% increase in developmental progress Harms: NR Modifiers: NR

Stigler et al., 2004

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Stigler et al., 2004 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: October 1997 to January 2002 Funding: National Alliance for Research in Schizophrenia and Depression. NIH. Department of Housing and Urban development Author industry relationship disclosures: NR Design: Retrospective case series | Intervention: Stimulants Recent trials: 2.5 mg orally (morning and noon) increased by 2.5 mg/week if needed Mean dosage ± SD (range) in mg/day & duration ± SD (range) in days: Methylphenidate (144 total trials): Dosage: 12.9 ± 11.4 (2.5–80) Duration: 545.1 ± 731.2 (1–3650) Amphetamine/dextroamp hetamine (68 total trials): Dosage: 10.4 ± 7.1 (2.5–45) Duration: 237.3 ±324.8 (1–1095) Dextroamphetamine (39 total trials): Dosage: 5.8 ± 2.8 (2.5–10) Duration: 196.5 ± 340.6 (7–1424) Pemoline (23 total trials) : Dosage: 33.3 ± 18.2 (18.5–75) Duration: 557.2 ± 889.1 (14–2492) Assessments: CGI-I administered pre-and post-trial (clinician and parent report) to determine improvement Groups: G1: Stimulants Co-interventions held stable during treatment: Yes Frequency of contact during study: NR | Inclusion criteria:; - Outpatients hospital-based autism treatment center; - Met DSM-IV criteria for PDD by one of two board-certified child and adult psychiatrist; - Recent or past stimulant trial; - Evaluated in clinic within Enrollment Period; Exclusion criteria: See inclusion criteria Age, mean/yrs ± SD (range) : G1: 7.26 ± 3.45 (2–19) Mental age: NR Gender: G1: M, n (%): 174 (89) F, n (%): 21 (11) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In-study Diagnostic tool/method: DSM-IV criteria clinical Diagnostic category, n (%): G1: Autistic disorder: 104 (53) Asperger’s disorder: 34 (17) PDD-NOS: 57 (29) Other characteristics, n (%): Mental retardation: 93 (48) | NR | Responders (CGI-I rating of 1 or 2), %: Patients with history of one stimulant trial: 24.6 Patients with history of two stimulant trials: 23.2 Patients with history of three stimulant trials responded to first trial: 11.1 Responders, n/N (%): (Did not respond to 1^st^ trial) 2^nd^ trial: 6/43 (14.05) 3^rd^ trial: 2/14 (14.3) Harms: Adverse Effects, n (%): Aggression: 15 (8) Agitation: 50 (26) Anxiety: 2 (1) Dyspepsia: 15 (8) Dysphoria: 23 (12) Insomnia: 10 (5) Irritability: 16 (8) Sedation: 2 (1) Tics: 9 (5) Weight loss: 14 (7) Total: 154/268 trials (57.5) Modifiers: PDD subtype (P < 0.013) Use of concomitant medication (P < 0.007)
| Concomitant therapies, n: Atypical antipsychotics: 14 Conventional antipsychotics: 4 Selective serotonin reuptake inhibitors: Other antidepressants: Imipramine: 2 Clomipramine: Nortriptyline: 1 Mirtazapine: 2 Venlafaxine: 1 Bupropion: 1 Mood stabilizers: 14 Alpha-2 adrenergic agonists: 17 Beta-adrenergic Antagonists: 2 N at enrollment: G1: 195 N at follow-up: G1: 195

Whitaker, 2004

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Whitaker, 2004 Country: UK Practice setting: Community Intervention setting: School Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: Case series, prospective | Intervention: Peer tutoring, 20 to 30 minutes on a weekly basis for 20 weeks, each pair involved in 20 to 24 play sessions Assessments: The fourth or fifth play session and a further completed session was videotaped after a minimum of 20 weeks; videotaped sessions were coded for joint attention, communication, and shared play. A semi-structured face-to-face interview was conducted by the author with each peer tutor in the final 3 weeks for the project. Groups: G1: peer tutoring Provider: Peer tutors, supervised by an experienced learning support assistant or nursery nurse Measure of treatment fidelity reported: NR Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 10 N at follow-up: G1: 9 (for coded variables) | Inclusion criteria:; - Attended village primary school with a unit for children with high levels of autism and moderate learning difficulties; Exclusion criteria:; - See inclusion criteria; Age, range (years): 6–7 Mental age: NR Gender, n: Male: 9 Female: 1 Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: ICD-10 Diagnostic category, %: Autism: 100 Other characteristics, n: CARS, severely autistic: 4/4 Complex utterances: 1 No language: 1 2 to 4 word sentences: 3 Mainly single words with infrequent simple word combinations: 5 Receptively at or above level of 3 information-carrying words: 2 Receptively at or below single-word stage: 2 Moderate to severe or severe levels of learning difficulty: 10 | Social skills: Joint attention, percent of coded intervals: G1: < 5 Communication/language: Requesting, percent of coded intervals: G1: < 3.5 Adaptive behavior: Shared play, mean percent: G1: 42 | Social skills: Joint attention, percent of coded intervals: G1: < 5 G1/BL: P = NS Communication/language: Requesting, percent of coded intervals: G1: 10 G1/BL: P < 0.025 Adaptive behavior: Shared play, mean percent: G1: 66 G1/BL: P = NS Harms: None Modifiers: NR

## 2003

Arick et al., 2003

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Arick et al., 2003 Country: US Practice setting: Academic Intervention setting: School Enrollment period: 1998 Funding: U.S. Department of Education Author industry relationship disclosures: NR Design: Prospective case series | Intervention: Study of Oregon regional programs for children with ASD designed to track educational progress of students receiving home or school based services over time. Assessments: Outcome data were collected at baseline and quarterly, biannually, and annually; measures included standardized tests, non-standardized forms, surveys, and interviews ASIEP-2, EOWPVT (if reached ceiling on vocal behavior subtest of ASIEP-2, quarterly), EBASAS (if reached ceiling on educational assessment of ASIEP-2, quarterly), Battelle Developmental Inventory (annually), VABS (annually), SLP, Program Implementation Checklist (at baseline & biannually), parent survey (annually), classroom observation form (annually) Groups: G1: children with ASD Provider:; - School based interventions tracked via a program implementation checklist; - Assessment specialists trained by special education professionals; Measure of treatment fidelity reported: No Co-interventions held stable during treatment: No | Inclusion criteria:; - Preschool students 2–6 years of age; - Primary diagnosis for services was ASD (confirmed by initial assessment results); - Nominated from Oregon regional programs for students with ASD; - Child already involved in some type of school and/or home behavioral program; Exclusion criteria:; - See inclusion criteria; Age, years, n: G1: 2: 9 3: 23 4: 22 5: 10 6: 3 Mental age: NR Gender: NR Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In Study Diagnostic tool/method: ASIEP Diagnostic category, n (%): ASD: 67 (100) Other characteristics: NR | Overall ratings: ASIEP-2 autism behavior checklist score, mean ± SD: Body/object use: G1: 12.03 ± 7.08 Language: G1: 14.07 ± 6.10 Total score: G1: 70.47 ± 19.82 ASIEP-2 educational assessment score, mean ± SD: Receptive language: G1: 4.98 ± 3.08 Expressive language: G1: 2.83 ± 2.78 Body concept: G1: 4.38 ± 3.80 Speech imitation: G1: 5.22 ± 3.40 Total score: G1: 28.82 ± 12.63 ASIEP-2 social interaction assessment score, mean ± SD: Appropriate social interactions: G1: 5.63 ± 5.27 Self-stimulation/nonresponsive to adult: G1: 22.86 ± 11.88 Total score: G1: 65.21 ± 15.35 ASIEP-2 vocal behavior score, mean ± SD: Noncommunicative utterances: G1: 35.97 ± 14.03 Unintelligible utterances: G1: 37.41 ± 14.08 Words used during sample: G1: 25.39 ± 36.0 Expressive language age: G1: 23.21 ± 8.50 | Overall ratings: ASIEP-2 autism behavior checklist score, 12–16 months, mean ± SD: Body/object use: G1: 9.90 ± 7.87 G1/BL: P ≤ 0.05 Language: G1: 12.23 ± 5.97 G1/BL: P ≤ 0.05 Total score: G1: 61.60 ± 25.86 G1/BL: P ≤ 0.05 ASIEP-2 educational assessment score, 12–16 months, mean ± SD: Receptive language: G1: 6.87 ± 3.50 G1/BL: P ≤ 0.01 Expressive language: G1: 4.63 ± 4.30 G1/BL: P ≤ 0.01 Body concept: G1: 7.27 ± 4.37 G1/BL: P ≤ 0.01 Speech imitation: G1: 7.37 ± 4.10 G1/BL: P ≤ 0.01 Total score: G1: 37.90 ± 15.44 G1/BL: P ≤ 0.01 ASIEP-2 social interaction assessment score, 12–16 months, mean ± SD: Appropriate social interactions: G1: 9.18 ± 8.15 G1/BL: P ≤ 0.01 Self-stimulation/nonresponsive to adult: G1: 17.37 ± 12.60 G1/BL: P ≤ 0.01 Total score: G1: 56.19 ± 18.60 G1/BL: P ≤ 0.01
| Concomitant therapies, n: Gluten-free and casein-free diet: 8 Secretin: 7 Vitamins: 6 Dimethylglycine: 5 ABA programs: 4 Magnesium: 3 B-6 vitamins: 3 Swimming: 3 Dairy-free diet: 3 Speech therapy: 3 Private preschool: 3 Gluten-free diet: 3 Yeast-free diet: 2 Audio sensory training: 2 Respite care: 2 In-home aide to assist with functional skills: 2 Occupational therapy: 2 19 others: 1 N at enrollment: G1: 67 N at follow-up: G1: 56 | | | ASIEP-2 vocal behavior score, mean ± SD: Noncommunicative utterances: G1: 23.17 ± 18.20 G1/BL: P ≤ 0.01 Unintelligible utterances: G1: 24.68 ± 20.43 G1/BL: P ≤ 0.01 Words used during sample: G1: 52.37 ± 52.32 G1/BL: P ≤ 0.01 Expressive language age: G1: 33.51 ± 16.70 G1/BL: P ≤ 0.01 Harms: NR Modifiers: Gain in expressive language age at follow-up was significantly correlated with follow-up IQ score (r = 0.469, P = 0.05), and Battelle Developmental Inventory cognitive domain age-equivalent scores at baseline (r = 0.498, P = 0.05) and follow-up (r = 0.511, P = 0.05).

Chez et al., 2003

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Chez et al., 2003 Country: US Practice setting: Specialty center Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: RCT | Intervention: Donepezil hydrochloride (DH), 6 weeks, QD, 2.5 mgs (dose was to 1.25 mgs if parents noted persistent GI distress or changes in behavior and discontinued if GI intolerability or behavior changes lasted > 1 day – considered an adverse event) Placebo: first 6 weeks of placebo then 6 weeks open label treatment for all subjects Assessments: Each completed at baseline and 6 weeks: ROWPVT 11 (clinician); EOWPVT-R (clinician); CARS (clinician and parent also completed at 12-week appointment) Groups: G1: DH capsule G2: placebo/DH capsule Co-interventions held stable during treatment: NR Frequency of contact during study: Testing administered at baseline, 6 weeks and 12 weeks; weekly phone logs Concomitant therapies, n (%): Anticonvulsants (divalproex sodium, valproic acid or lamotrigine): G1: 20 G2: 12 Corticosteroids (pulse dose prednisone or prednisolone): G1: 4 G2: 2 | Inclusion criteria:; - Ages 2–10 years; - Prior diagnosis of AD, decreased PDD-NOS, or Landau-Kleffner Syndrome; Exclusion criteria:; - Concomitant neurological syndrome or disease with neurological compromise (e.g., neurofibromatosis); Age, years (range): G1: 6.8 (2.1–9.9) G2: 6.9 (4.1–10.3) Mental age: NR Gender, n (%): Male: G1: 19 (83) G2: 16 (80) Female: G1: 4 (17) G2: 4 (20) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In Study Diagnostic tool/method: DSM-IV Diagnostic category, n: Autistic disorder: G1: 8 G2: 5 PDD-NOS: G1: 14 G2: 13 Landau-Kleffner syndrome: G1: 1 G2: 2 Other characteristics, n (%): Nocturnal epileptiform EEG abnormalities: 28 (72) Normal 24 EEG patterns: 11 (28) | Overall ratings: CARS score, mean ± SD: G1: 34.7 ± 7.7 G2: 35.1 ± 7.9 G1/G2: P = NS Communication/language: EOWPVT-R score, mean ± SD: G1: 35.7 ± 27.8 G2: 31.9 ± 31.1 G1/G2: P = NS ROWPVT 11 score, mean ± SD: G1: 38.8 ± 23.5 G2: 33.5 ± 27.9 G1/G2: P = NS | Overall ratings: CARS score, 6 weeks, mean ± SD: G1: 33.3 ± 8.0 G2: 32.9 ± 7.7 G1/BL: P = NS G2/BL: P < 0.05 G1/G2: P = NS CARS, 12 weeks, mean ± SD: G1: 30.8 ± 7.9 G2: 30.9 ± 9.1 G1/BL: P < 0.05 G2/BL: P < 0.05 G1/G2: P = NS Communication/language: EOWPVT-R score, 6 weeks, mean ± SD: G1: 43.3 ± 27.2 G2: 33.8 ± 32.9 G1/BL: P < 0.05 G2/BL: P = NS G1/G2: P = NS EOWPVT-R score, 12 weeks, mean ± SD: G1: 42.5 ± 28.5 G2: 40.9 ± 38.8 G1/BL: P < 0.05 G2/BL: P < 0.05^**^ G1/G2: P = NS ROWPVT 11 score, 6 weeks, mean ± SD: G1: 50.3 ± 27.0 G2: 39.83 ± 27 G1/BL: P < 0.05 G2/BL: P = NS G1/G2: P = NS ROWPVT 11 score, 12 weeks, mean ± SD: G1: 49.7 ± 34.2 G2: 87.37 ± 14.2 G1/BL: P < 0.05^**^ G2/BL: P < 0.05^***^ G1/G2: P = NS
Author: Chez et al., 2003 Country: US Practice setting: Specialty center Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: RCT | CNS stimulants (dextroamphetamine/amphetimine or methylphenidate): G1: 5 G2: 3 Antidepressants (fluoxetime hydrochloride or paroxitene): G1: 2 G2: 5 Antipsychotics (risperidone):^*^ G1: 4 G2: 4 Alpha adrenergic blocking agents (clonidine): G1: 1 G2: 8 N at enrollment: G1: 23 G2: 20 N at follow-up: G1: 17 G2: 17 | | | Harms: First 6 weeks: Increased irritability, mood swings, crying, lability: G1: 5 G2: 0 Lethargy: G1: 1 G2: 0 Frequent urination: G1: 1 G2: 0 Troubled sleep: G1: 1 G2: 0 Second 6 weeks: Diarrhea, stomach cramping: G1: 2 G2: 0 Increased irritability, mood swings, crying, lability: G1: 4 G2: 2 More stimming: G1: 1 G2: 0 Withdrawal due to adverse events, n: G1: 6 G2: 0 Withdrawal due to no show, 6 week appointment, n: G1: 0 G2: 3 Modifiers: NR

Comments:

* The paper also reports the total number of children in G1 and G2 on antipsychotics is 4, so these numbers may be in error.

** Change is statistically significant when compared to BL or 6 month value.

*** Change is statistically significant when compared to 6 month value.

Evangeliou et al., 2003

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Evangeliou et al., 2003 Country: Greece Practice setting: Academic Intervention setting: Clinic Enrollment period: May 1999 to May 2000 Funding: NR Author industry relationship disclosures: NR Design: Prospective case series | Intervention: Ketogenic diet (John Radcliffe diet) Applied for 6 months, with continuous administration for 4 weeks, interrupted by 2 week diet-free intervals Assessments: CARS at baseline and following intervention Groups: G1: Ketogenic diet Co-interventions held stable during treatment: NR Frequency of contact during study: End of each 4 week diet phase and at the end of each 2 week diet-free phase Monthly Psychiatric examination at the end of the diet and every month after discontinuation of diet for 6 months Concomitant therapies, n (%): Haloperidol: 30 (100) N at enrollment: G1: 30 N at follow-up: G1: 30 | Inclusion criteria:; - 4–10 years of age with autistic behavior as diagnosed by a child psychiatrist according to CARS; - Mild-moderate cases=CARS 30–36; - Severe cases= CARS ≥ 37; Exclusion criteria: See inclusion criteria Age, median/yrs (range): 7 (4–10) Mental age: NR Gender: M, n (%): 16 (53.3) F, n (%): 14 (46.7) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: CARS Diagnostic category, n (%): Autism : 30 (100) Other characteristics: NR | Overall ratings: CARS, n, mean ± SD: Mild/Moderate autistic cases: 2 (CARS=34, 36) Severe cases: 28 (CARS: 37–54) Pre-CARS: 2, 35 ± 1.41 Pre-CARS: 8, 41.88 ± 3.14 Pre-CARS: 8, 45.25 ± 2.76 Elevated 3-ohisovaleric acid: 3 Pathologic levels of beta - hydroxybutyrate abnormal (1.05 – 1.45 mmol/L): 6 | Overall ratings: CARS, mean ± SD: Improvement: 4.77 ± 0.89 P < 0.001 Significant improvement observed in those with lower initial CARS scores Diet tolerated, n (%): 23 (76.6) Improvement in Social behavior, interactions, speech, stereotypy & learning, n (%): 18 (60) Elevated beta-OHb following diet, n (%): 4 (13.3) Interrupted diet, n (%): 5 (16.7) Elevated beta-OHb following diet, n (%): 2 (6.7) Improvement significantly (CARS > 12 units): 2 (CARS=16, 13 units) Average (CARS > 8–12 units): 8 (CARS mean=7.1 units) Minor (CARS 2–8 units): 8 (CARS mean =7.1 units)
| | | | Among 6 with the pathologic levels of beta - hydroxybutyrate, improvement, n: Significant: 1 Average: 2 Minor: 1 (2 discontinued the diet) Harms: NR Modifiers: NR

Levy et al., 2003

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Levy et al., 2003 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NIH, MRDDRC Author industry relationship disclosures: NR Design: RCT (double-blind cross-over) | Intervention: Single IV dose of human synthetic secretin (2CU/kg) to a maximum dose of 75 CU injected slowly over 1 minute Infusions separated by a 6-week washout period Assessments: GBRS completed by families and teachers or therapists; daily log of gastrointestinal symptoms completed by parents; CSBS completed by study examiners at BL and two weeks after each infusion; Ritvo Real-life Rating Scale completed by study examiners at BL and two weeks after each infusion; occurrence of adverse effects monitored throughout the study Groups: G1: infusion of secretin followed by placebo six weeks later G2: infusion of placebo followed by secretin six weeks later Co-interventions held stable during treatment: NR Frequency of contact during study: Families & teachers or therapists completed GBRS weekly Concomitant therapies, n: Prozac: G1: 3^*^ G2: 1 Adderall: G1: 0 G2: 2 Risperidone G1: 1 G2: 0 Guanfacine: G1: 1^*^ G2: 2 | Inclusion criteria:; - Children in the age range of 3–8 years with ASD as diagnosed by ADI-R; Exclusion criteria:; - Significant hearing or vision loss; - Other neurological disorders (e.g., cerebral palsy, phenylketonuria, tuberous sclerosis, neurofibromatosis, seizure disorder); - Genetic disorder; - Prematurity (< 32 weeks gestation); - Diagnosis of coeliac disease or other gastrointestinal disease, associated with malabsorption; - Previous treatment with secretin; - Anaemia and plumbism; Age, months ± SD: G1: 70.65 ± 18.2 G2: 76.53 ± 14.33 Age, range: 43–103 Mental age: NR Gender, %: Male: G1: 87 G2: 74 Female: G1: 13 G2: 26 Race/ethnicity, %: Caucasian: G1: 87 G2: 94 SES: Maternal education: NR Household income: NR Diagnostic approach: In Study Diagnostic tool/method: ADI-R | Overall ratings: CARS total score, mean ± SD: G1: 34.1 ± 3.13 G2: 37.32 ± 6.23 G1/G2: P = 0.02 CARS score < 37 (mild-moderate), %: G1: 84 G2: 55 G1/G2: P = 0.003 Adaptive behavior: VABS communication standard score, mean ± SD: G1: 54.50 ± 14.03 G2: 54.44 ± 13.81 G1/G2: P = NS CSBS standard score, mean ± SD: G1: 72.75 ± 7.86 G2: 75.03 ± 10.65 G1/G2: P = NS Ritvo subscale score, mean ± SD: Sensory motor: G1: 0.46 ± 0.06 G2: 0.41 ± 0.06 G1/G2: P = NS Social relatedness: G1: 1.03 ± 0.06 G2: 1.16 ± 0.06 G1/G2: P = NS Affect: G1: 0.64 ± 0.10 G2: 0.74 ± 0.10 G1/G2: P = NS Sensory: G1: 0.61 ± 0.05 G2: 0.68 ± 0.05 G1/G2: P = NS Language: G1: 0.80 ± 0.04 G2: 0.88 ± 0.05 G1/G2: P = NS | Adaptive behavior: CSBS standard score, period 1, mean change ± SD: G1: 0.14 ± 8.28 G2: −0.27 ± 7.36 CSBS standard score, period 2, mean change from BL ± SD: G1: 2.19 ± 7.73 G2: −0.70 ± 7.90 Ritvo global score, period 1, mean change ± SD: G1: 0.01 ± 1.35 G2: −0.18 ± 0.79 Ritvo global score, period 2, mean change from BL ± SD: G1: 0.12 ± 0.66 G2: −0.27 ± 0.96 GBRS score, teacher-rated, period 1, mean change ± SD: G1: 0.34 ± 0.72 G2: 0.14 ± 0.71 GBRS score, teacher-rated, period 1, mean change ± SD: G1: 0.33 ± 1.01 G2: 0.29 ± 1.06 GBRS score, parent-rated, period 1, mean change ± SD: CARS < 37: G1: 0.20 ± 0.76 (n=25) G2: 0.30 ± 0.71 (n=14) CARS ≥ 37: G1: 0.73 ± 0.60 (n=5) G2: 0.14 ± 0.58 (n=16)
| Methylphenidate: G1: 0 G2: 2 N at enrollment: G1: 31 G1a: 26 G1b: 5 G2: 31 G2a: 16 G2b: 15 N at follow-up: G1: 30 G1a: NR G1b: NR G2: 31 G2a: 16 G2b: 15 | Diagnostic category, n (%): Autism: 61 (100) PDD-NOS: NR Aspergers: NR Other characteristics, %: GI symptoms: G1: 63 G2: 50 | | GBRS score, parent-rated, period 2, mean change from BL ± SD: CARS < 37: G1: 0.74 ± 0.86 (n=24) G2: 0.19 ± 1.08 (n=13) CARS ≥ 37: G1: 0.00 ± 0.42 (n=5) G2: 0.30 ± 0.70 (n=16) Harms: Adverse events, n: Elevated LFT: 3 Hyperactivity: 2 Emotional lability: 1 Fractures: 2 Stomach ache: 1 Modifiers: CARS by treatment interaction for parent-rated GBRS (P = 0.0001)

Comments:

* One child in G1 received both prozac and guanfacine.

Magiati et al., 2003

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Magiati et al., 2003 Country: UK Practice setting: Academic Intervention setting: School Enrollment period: NR Funding: Agency: Three Guineas Trust, UK Author industry relationship disclosures: NR Design: Prospective case series | Intervention: Picture Exchange Communication system (PECS). Assessment carried out in the 2 month period prior to training with rates of change measured during 2 month periods over 6 months following training ( time1/BL, time2, time3, time 4) Assessments: Teachers completed initial measures of children’s communicative ability 2 mos before onset of PECS training; same assessments completed immediately after PECS workshop and at 2 monthly intervals thereafter ASQ, VABS, ATEC Parental information on child’s general level of functioning and severity of autistic symptoms prior to onset of PECS training Groups: G1a: Initially using little/no speech G1b: Vocabulary of > 10 words when training began Provider: Teachers Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: None N at enrollment: G1a: 18 G1b: 16 | Inclusion criteria:; - Diagnosis of Autism; - Special schools with a full dedicated provision for children with ASD; - No or minimal prior experience of PECS; Exclusion criteria:; - Very well developed verbal skills; - Any increase of Behavioral difficulties; - See inclusion criteria; Age, mean/yrs ± SD (range): Both groups: 7.66 ± 2 (5–12) Mental age: NR Gender: M, n (%): 29 (85.3) F, n (%): 5 (14.7) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In Study/Referral: Referral Diagnostic tool/method: ADI-R Diagnostic category, n (%): Autism : 34 (100) G1a: 18 G1b: 16 | Vineland scores: Age equivalent, mean/yrs:mos ± SD, (range): Communication: 1:6 ± 7, (0:8–2:8) Daily living skills: 2:7 ± 7, (1:4–3:9) Socialization: 1:6 ± 7, (0:7–2:10) PECS, mean ± SD: Level: 0.91 ± 1.26 Vocabulary: 0.85 ± 1.18 Frequency: 1.65 ± 1.89 Number of signs: 1.18 ± 1.31 Number of words: 2.53 ± 2.19 Number of phrases: 1 ± 1.58 Overall level of spontaneous communication: 5.91 ± 2.02 Rimland Autism Treatment Evaluation Checklist, mean ± SD: Total score: 74.9 ± 20.98 Communication: 19.50 ± 5.43 Socialization: 16.02 ± 8.05 Sensory/cognitive: 22.58 ± 6.37 Physical/mood: 16.76 ± 7.38 | Vineland scores: NR PECS, mean ± SD: Level: 4.58 ± 1.26 (P = 0.001) Vocabulary: 4.31 ±1.12 (P = 0.001) Frequency: 4.71 ±1.59 (P = 0.001) Number of signs: 1.62 ± 1.56 (P = 0.01) Number of words: 3.21 ± 2.01 (P = 0.001) Number of phrases: 1.53 ± 1.98 (P = 0.02) Overall level of spontaneous communication: 7.38 ±1.47 (P = 0.001) Rimland Autism Treatment Evaluation Checklist, mean ± SD: Total score: 65.11 ± 20.89 Communication: 17.29 ± 5.45 Socialization:13.97 ± 7.13 Sensory/cognitive: 19.00 ± 7.97 (P < 0.01) Physical/mood: 14.85 ± 7.1 Harms: NR Modifiers: Changes according to initial language level: Baseline vs. Follow up, mean ± SD:
| N at follow-up: G1a: 18 G1b: 16 | Other characteristics, n (%): Hyperactivity: 1 (2.9) Non-verbal: 10 (29.4) Single words: 10 (29.4) Phrase speech: 14 (41.2) | | G1a: PECS Level: 1.3 ± 1.13 vs. 4.0 ± 1.14 Vocabulary: 1.05 ± 0.87 vs. 4.06 ± 0.94 Frequency: 2.4 ± 1.76 vs. 4.4 ± 1.61 [all 3 P < 0.01] Overall level of spontaneous communication: 4.94 ± 1.55 vs. 6.39 ± 1.14 P < 0.001 Number of signs: P < 0.03 Number of words: P = 0.001 G1b: PECS Level: <1 vs. 5.3 P < 0.001 Pictures used: <1 to 21–50 P < 0.001 Frequency of PECS use <1 to 11–20 symbols P < 0.001 Number of words P = NS Number of phrases P = NS Number of signs: P = NS Overall level of spontaneous Communication: 6.9 ± 2.01 vs. 8.47 ± 0.91 P < 0.001
| | | | Prior exposure to PECS: experienced group vs. naïve group: Experienced: PECS Freqs : baseline vs. follow-up P = NS PECS vocabulary: P = 0.02 Naïve group: PECS level, freq, vocabulary all rose significantly between times 1 & 4 (P < 0.001) School differences: pupils in schools with little or no prior experience of PECS actually reached higher PECS levels at follow-up than pupils in schools where PECS was already established

Masi et al., 2003

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Masi et al., 2003 Country: Italy Practice setting: Third level research Hospital Intervention setting: Clinic Enrollment period: March 1999 to April 2002 Funding: NR Author industry relationship disclosures: First author-Eli Lilly, Pfizer, GlaxoSmithKline & Janssen Design: Prospective case series | Intervention: Risperidone monotherapy. Duration of treatment ranged from 3–32 months. Started on a dose of 0.25 mg at bedtime. Subsequent titration was by 0.25mg increments at no more than weekly intervals depending on clinical response and occurrence of side effects. Max daily dose was 1mg. Assessments: CPRS, CGI-I, CGAS, and side effects checklist administered by independent examiners at baseline, after 8 wks, and at irregular intervals during follow up (mean follow up 7.9±6.8 mos, range 1–32 mos). CARS, Griffiths Developmental Scales, Leiter International Performance Scale administered at baseline. Groups: G1a: Autistic disorder G1b: PDD-NOS Co-interventions held stable during treatment: NR Frequency of contact during study: Behavioral symptoms at baseline, after 8 weeks and again at irregular intervals during follow-up. Concomitant therapies: None N at enrollment: 53 N at follow-up: 47 (treated with risperidone for at least 2 mos) | Inclusion criteria:; - Diagnosis of autistic disorder or PDD-NOS according to DSM-IV criteria and CARS score above 30; - Absence of comorbid medical or neurologic conditions; - Severe behavioral symptoms; - Written parental informed consent to treatment; Exclusion criteria: See inclusion criteria Age, mean/yrs ± SD: 4.6 ± 0.7 (3.6–6.6) G1a: 4.4 ± 0.6 G1b: 5 ± 0.8, P = 0.01 Mental age: NR Gender: M, n (%): 45 (84.9) F, n (%): 8 (15.1) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In Study Diagnostic tool/method: Clinical interview, DSM-IV, CARS score above 30 Diagnostic category, n (%): Autism : 37 (69.8) PDD-NOS : 16 (30.2) Other characteristics, n (%): Mental retardation: 43 (81) Mild: 10 Moderate: 21 Severe: 12 | Overall ratings: CPRS, mean ± SD: Total: 51.07 ± 5.2 G1a: 51 ± 5.9 G1b: 41.8 ± 4.6 P < 0.0001 22 with a CGI-I score of 1/2 showed at least a 25% reduction in CPRS total score and were considered responders Among responders (n=22): CARS : 40.1 ± 7 CPRS: 50.5 ± 6.0 Among non-responders (n=25): CARS: 42.7 ± 5.2 CPRS: 50.7 ± 5.4 Prolactin level, ng/ml. mean ± SD: 13.3 ± 7.8 CARS: G1a: 43.9 ± 5.3 G1b: 35.9 ± 4.0 P < 0.0001 CGAS, mean ± SD: Overall: 20.87± 4.6 G1a: 19.6 ± 4.0 G1b: 23.9 ± 4.6 P = 0.002 Responders/non-responders: G1a: 12/21 G1b: 10/4 P = 0.06 Weight in kg, mean ± SD: Overall: 20.6 ± 5.5 G1a: 19.1 ± 5.0 G1b: 22.9 ± 4.3 P = 0.02 | Overall ratings: CGAS, mean ± SD: G1a: 27.1 ± 5.9 G1b: 33.4 ± 4.7 P < 0.0001 CPRS, mean ± SD: G1a: 42.5 ± 5.4 G1b: 34.6 ± 3.2 P < 0.0001 Serum Prolactin level, mean ± SD: Responders: 24.3 ± 16.3 Non-responders: 27.5 ± 23.2 (P = 0.64) Prolactin level at last observation: 28.38 ± 22.45 (t = − 3.8, df = 72, P < 0.0001) G1a: 29 ± 21.3 G1b: 26.1 ± 26.0 P = 0.70 Weight in kg, mean ± SD: Overall: 23.3 ± 6.3 G1a: 21.5 ± 5.9 G1b: 26.1 ± 5.3 P = 0.02 Responders/non-responders: mean ± SD: Maximum dosage-mg/d: 0.70 ± 0.18/0.57 ± 0.16 (P = 0.012) Optimal dosage, mg/d: 0.61 ± 0.22/0.49 ± 0.16 (P = 0.036) Duration of treatment (mo): 11.3 ± 8.1/6.5 ± 4.3 (P = 0.013)
| | | | Weight gain, kg: 3.61 ± 3.40/1.76 ± 1.98 (P = 0.026) CPRS(total score): 40.44 ± 5.9, 21% improvement from baseline, P < 0.0001 >30% improvement, %: Hyperactivity: 34 Fidgetiness: 33 Angry effect: 31 Liability of affect: 31 > 20% improvement, %: Negative uncooperative behavior: 27.1 Withdrawal: 26 Non-spontaneous relation with examiner: 20 Rhythmic motions: 21 CGI-I score, n: Very much/much improved: 22 Minimally improved: 22 Unchanged: 3 CGAS, mean ± SD (%) improvement: 29.2 ± 6.2 (28), (t = −15.423, P < 0.0001)
| | | | Harms: 12 (22.6 %) discontinued treatment due to side effects (6 due to increased prolactin levels Other causes: loss of consciousness with suspected epileptic seizure, dystonic episode, tachycardia and fushes, subjective vision disorders) Side effects that did not cause discontinuation of treatment, n : Increased appetite: 8 Agitation:4 Enuresis: 4 Decreased appetite : 2 Sedation & hypoactivity: 3 Tremors: 2 Elevated liver enzymes: 1 Increase of platelets > 500,000/mm: 1 Mean weight gain in the total sample: 2.4 ± 2.8 kg Modifiers: See above for the effect by Diagnosis type (G1a/G1b) Drug response not affected by severity of mental retardation

Sofronoff et al., 2003

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Sofronoff et al., 2003 Country: Australia Practice setting: NR Intervention setting: Clinic Enrollment period: NR Funding: School of Psychology, University of Queensland Author industry relationship disclosures: NR Design: RCT | Intervention: A cognitive behavior therapy program “Exploring Feelings,” taught in 6 weekly two-hour sessions; treatment goal: teach strategies to manage feelings and broaden emotional and behavioral repertoire Two therapists per group of three children; while children in the group with parents involved received the intervention, their parents worked through the “Expoloring Feelings” program with therapists Assessments: James and the Maths Test (child measure developed for the study), parent measure of self efficacy in management of 15 behaviors related to Asperger; given pre-intervention, post-intervention, and at 6 week follow-up. Parent evaluation of intervention assessed at 6 week follow-up Groups: G1: behavior therapy, parents not involved G2: behavior therapy, parents taught separately G3: waitlist controls Provider: Clinical psychologists Measure of treatment fidelity reported: Yes Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 24 G2: 27 G3: 14 | Inclusion criteria:; - Age 10–12 years; - Diagnosis of Asperger syndrome; - Presence of anxiety based on parental report; Exclusion criteria:; - See inclusion criteria; Age: NR Mental age: NR Gender: NR Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: NR Diagnostic category, n (%): Aspergers: 65 (100) Other characteristics: NR | Problem behavior: James and the Maths Test score, mean: G1: NR^*^ G2: NR^*^ G3: NR^*^ G1/G2/G3: P = NS Parental self efficacy rating, mean: G1: NR^**^ G2: NR^**^ G3: NR^**^ G1/G2/G3: P = NS | Problem behavior: James and the Maths Test score, mean: Post-treatment: G1: NR^*^ G2: NR^*^ G3: NR^*^ G1/G2: P < 0.01 G1/G3: P < 0.0001 G2/G3: P < 0.0001 6 week follow-up: G1: NR^*^ G2: NR^*^ G3: NR^*^ G1/G2: P < 0.0001 G1/G3: P < 0.0001 G2/G3: P < 0.0001 Parental self efficacy rating, mean: G1: NR^**^ G2: NR^**^ G3: NR^**^ Post-treatment: G1: NR^*^ G2: NR^*^ G3: NR^*^ G1/G2: P = NS G1/G3: P < 0.05 G2/G3: P < 0.05 6 week follow-up: G1: NR^*^ G2: NR^*^ G3: NR^*^ G1/G2: P = NS G1/G3: P < 0.05 G2/G3: P < 0.05 Harms: NR Modifiers: NR
| N at follow-up: NR

Comments:

* data only illustrated graphically in Figure 1

** data only illustrated graphically in Figure 2, which appears to erroneously be a reproduction of Figure 1

## 2002

Bibby et al., 2002

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Bibby et al., 2002 Country: UK Practice setting: Academic Intervention setting: Home Enrollment period: September 1998 to May 2000 Funding: Autism and Developmental Disorders Education Research Ltd. Author industry relationship disclosures: NR Design: Prospective case series | Intervention: Parent-managed behavioral intervention patterned after UCLA workshop model Groups: G1: intervention G1a: children with an early (before or within 3 months of intervention start) IQ score G1b: children with an early (before or within 3 months of intervention start) VABS G1c: children at a minimum age of 72 months after at least 24 months behavioral intervention Assessments: Conducted by seven psychology graduates with ≥ 12 months post-graduate experience working with children with autism with same age range as groups IQ scores (assessed by primary assessors, research assistants, third author and psychologist), Bayley Scales of Infant Development (2^nd^ ed.), WPPSI-R, WISC-III, Reynell Developmental Language Scales (3^rd^ EK ed.), VABS (survey form from Interview Edition (assessed by trained rater), ADI-R (assessed by research assistants) Provider: Parent-managed approach with care provided by consultants, family members, and volunteers (19–20% UCLA Level II, 29–35% PhD or registered clinical psychologist level without meeting UCLA criteria, 47–51% MA or BA level paraprofessionals) | Inclusion criteria:; - Children with autism whose parents who sought legal advice from the first author concerning public funding for behavioral interventions; Exclusion criteria:; - Unable to arrange for assessment; - Additional diagnosis of cerebral palsy; - Rett’s disorder; Age, mean months ± SD: Study entry: G1a: 43.4 ± 12.6 Follow-up: G1c: 85.5 ± 11.7 Mental age, months: G1a: 21.3 (n=17) Gender, n: Male: 55 Female: 11 Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: NR Diagnostic category, n (%): Autism: 58 PDD-NOS: 2 Aspergers: 0 Other characteristics: Age at beginning of treatment, months ± SD: 45.0 ± 11.2 Duration of behavioral treatment at time of study entry, n (%): < 12 months: 11 (18) 12–24 months: 31 (52) > 24 months: 18 (30) | Overall ratings: Sum pathology score, early, mean points: G1: 4.9 Social skills: VABS socialization score, mean: G1: 62.8 VABS socialization, developmental age, months: G1: 26.3 Communication/language: VABS communication score, mean: G1: 66.9 VABS communication, developmental age, months: G1: 35.2 Reynell developmental language scale, months: Comprehension: G1: 31.9 Expressive: G1: 31.2 Adaptive behavior: VABS composite score, early, mean: G1b: 54.5 VABS composite score, mean: G1: 58.8 VABS composite, developmental age, months: G1: 31.8 VABS daily living score, mean: G1: 59.0 VABS daily living, developmental age, months: G1: 33.7 | Overall ratings: Sum pathology score, 12 months, mean points: G1: 2.2 G1/BL: P < 0.01 Social skills: VABS socialization score, 12 months, mean: G1: 65.9 G1/BL: P = NS VABS socialization, 12 months, developmental age, months: G1: 36.2 G1/BL: P < 0.01 Communication/language: VABS communication score, 12 months, mean: G1: 70.3 G1c: 66.3 G1/BL: P < 0.05 VABS communication, 12 months, developmental age, months: G1: 47.5 G1c: 63.0 G1/BL: P < 0.01 Reynell developmental language scale, 12 months, months: Comprehension: G1: 37.5 G1/BL: P < 0.01 Expressive: G1: 35.7 G1/BL: P < 0.01 Adaptive behavior: VABS composite scores, 12 months, mean: G1: 61.0 G1b: 63.4 G1c: 55.2 G1/BL: P = NS
| Measure of treatment fidelity reported: No Co-interventions held stable during treatment: No Concomitant therapies, %: At least one other intervention chosen by parents (e.g., diets, vitamins, minerals, secretin, homeopathic preparations, sensory treatments): 81 N at enrollment: G1: 75 G1a: 22^*^ G1b: 21^*^ N at follow-up: G1: 60 G1c: 42^*^ | Secondary diagnoses of additional neurological disorders or epilepsy, n: 0 Hours of one-to-one treatment received at follow-up, mean ± SD: G1c: 4743 ± 1508 Weekly hours of one-to-one treatment received at follow-up, mean ± SD: G1c: 23.7 ± 10.4 Duration of treatment at follow-up, months ± SD: G1c: 36.8 ± 10.3 Weekly hours of school attendance at follow-up, mean ± SD: G1c: 15.9 ± 11.0 School placement at follow-up, n:^**^ Attending special education setting with one-on-one assistance: 9 Attending special education setting with no one-on-one assistance: 4 Mainstream for at least part of school week with full-time individual adult support: G1c: 23 Mainstream for at least part of school week with part-time individual adult support: G1c: 2 Mainstream for at least part of school week with no individual adult support (educationally normal functioning): G1c: 0 | VABS maladaptive behavior score, mean: G1: 16.3 Educational/cognitive/academic attainment: IQ, early, mean: G1a: 50.8 IQ, mean: G1: 57.6 Mental age, months: G1: 34.0 Merrill-Palmer mental age, mean months: G1: 48.8 | VABS composite, 12 months, developmental age, months: G1: 41.4 G1/BL: P < 0.01 VABS daily living score, 12 months, mean: G1: 56.9 G1c: 50.4 G1/BL: P = NS VABS daily living, 12 months, developmental age, months: G1: 41.3 G1/BL: P < 0.01 VABS maladaptive behavior score, 12 months, mean: G1: 15.2 G1/BL: P = NS Educational/cognitive/academic attainment: IQ, 12 months, mean: G1: 58.5 (n=58) G1a: 55.0 G1/BL: P = NS IQ > 85, 12 months, n: G1: 10/66 IQ, 12 months, mean ± SD (95% CI) G1c: 53.1 ± 20.0 (46.8–59.4) Merrill-Palmer mental age, 12 months, mean months: G1: 55.6 G1c: 58.3 G1/BL: P < 0.01 Mental age, 12 months, months: G1: 39.4 (n=51) G1/BL: P < 0.01
| | | | Harms: NR Modifiers: There was a significant correlation between early IQ and IQ at study entry and 12 months (both r = 0.78) and between IQ at study entry and IQ at 12 months (r = 0.93). VABS composite scores at study entry and 12 months were significantly correlated (r = 0.91), but not with early VABS composite score. Change in IQ from early measure to study entry was predicted only by age at start of behavioral treatment (r = − 0.39, P = 0.04). There was no effect of group level of consultants on changes in IQ and VABS scales from study entry to 12 months.

Comments:

* There were 12 children in both G1a and G1c and 9 children in both G1a and G1b. Means and variances were not significantly different between G1a and G1b, so the authors considered these values as representative for the overall group of participants at baseline.

** Among 6 who had ceased to receiving EIBI before follow-up, 5 were receiving special needs school education and 1 had no school placement.

Chez et al., 2002

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Chez et al., 2002 Country: US Practice setting: Specialty treatment center Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: double Blind RCT | Intervention: 800 mg of L-Carnosine daily for 8 weeks Assessments: Baseline & 8-weeks: expressive language (EOWPVT), receptive language (ROWPVT), autism severity ratings (CARS & GARS), and CGI of Change; all completed by parents in a pediatric neurology clinic in a room dedicated to assessment Every two weeks, parents faxed a CGI of Change; they were not allowed to refer back to faxes from the prior 2-week period Groups: G1: L-Carnosine G2: Placebo Co-interventions held stable during treatment: NR Frequency of contact during study: every 2 weeks Concomitant therapies, n (%): Valproic acid: NR N at enrollment: G1: 14 G2: 17 N at follow-up: G1: 14 G2: 17 | Inclusion criteria:; - Age 3–12 years; - Prior diagnosis of ASD, PDD by DSM-IV-Revised; Exclusion criteria:; - Family HX of seizure disorder or fragile X syndrome, or other genetic disorder or; - etiology of their spectrum disorder; Age, mean/months ± SD: G1: 85.69 ± 24.57 G2: 92.47 ± 28.95 Mental age: NR Gender: M, n (%): 21 (67.7) F, n (%): 10 (32.3) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In study Diagnostic tool/method: DSM-IV Diagnostic category, n (%): Autism/PDD-NOS: 31 (100) Other characteristics: NR | Overall ratings: Clinical Global Impression, mean ± SD: G1: 14.50 ± 3.65 G2: 12.94 ± 4.18 P = NS Childhood Autism Rating Scale, mean ± SD: G1: 31.71 ± 6.55 G2: 34.85 ± 6.69 P = NS Gilliam Autism Rating Scale, mean ± SD: G1: 55.50 ± 16.35 G2: 50.88 ± 16.96 P = NS Communication/language: Expressive One-Word Picture Vocabulary test (raw), mean ± SD: G1: 35.36 ± 20.87 G2: 30.65 ± 26.28 P = NS Expressive One-Word Picture Vocabulary test (age adjusted), mean ± SD: G1: 40.71 ± 23.44 G2: 35.41 ± 29.94 P = NS Receptive One-Word Picture Vocabulary test (raw), mean ± SD: G1: 38.00 ± 23.67 G2: 34.29 ± 28.56 P = NS Receptive One-Word Picture Vocabulary test (age adjusted), mean ± SD: G1: 40.57 ± 24.55 G2: 39.65 ± 27.91 P = NS | Overall ratings: Changes in children after 8 wks on Active Carnosine: Clinical Global Impression, mean ± SD(baseline vs. 8 wk): G1: 16.39 ± 4.36 P = 0.06 Clinical Global Impression, mean ± SD(2 wk vs. 6 wk): G1: 4.92 ± 5.69 P = 0.04 Changes in children after 8 wks on Active Carnosine: Childhood Autism Rating Scale, mean ± SD: G1: 29.75 ± 7.53 P = 0.07 Gilliam Autism Rating Scale, mean ± SD: G1: 44.35 ± 14.93 P = 0.01 Changes in children after 8 wks on Active Carnosine: Expressive One-Word Picture Vocabulary test (raw), mean ± SD: G1: 37.28 ± 25.66 P = NS Expressive One-Word Picture Vocabulary test (age adjusted), mean ± SD: G1: 43.78 ± 28.22 P = NS
| | | GARS Communication Scale, mean ± SD: G1: 21.64 ± 7.99 G2: 15.23 ± 6.68 P = 0.02 Adaptive behavior: GARS Behavior Scale, mean ± SD: G1: 15.71 ± 6.65 G2: 17.17 ± 8.71 P = NS Social skills: GARS Socialization Scale, mean ± SD: G1: 18.14 ± 6.30 G2: 18.47 ± 6.40 P = NS | Receptive One-Word Picture Vocabulary test (raw), mean ± SD: G1: 44.64 ± 26.56 P = 0.01 Receptive One-Word Picture Vocabulary test (age adjusted), mean ± SD: G1: 47.86 ± 28.37 P = 0.01 GARS Communication Scale, mean ± SD: G1: 18.14 ± 6.27 P = 0.03 Adaptive behavior: GARS Behavior Scale, mean ± SD: G1: 12.86 ± 5.95 P = 0.04 Social skills: GARS Socialization Scale, mean ± SD: G1: 13.36 ± 6.58 P = 0.01 Changes in children after 8 wks on Placebo:
| | | | Clinical Global Impression, mean ± SD (baseline vs. 8 wk): G2: 14.25 ± 4.51 P = NS Clinical Global Impression, mean ± SD( 2 wk vs. 6 wk) : G2: 4.71 ± 5.02 P = NS Childhood Autism Rating Scale, mean ± SD: G2: 33.76 ± 6.54 P = NS Gilliam Autism Rating Scale, mean ± SD: G2: 49.88 ± 16.80 P = NS Communication/language: Expressive One-Word Picture Vocabulary test (raw), mean ± SD: G2: 31.65 ± 29.19 P = NS Expressive One-Word Picture Vocabulary test (age adjusted), mean ± SD: G2: 37.12 ± 33.38 P = NS Receptive One-Word Picture Vocabulary test (raw), mean ± SD: G2: 37.11 ± 30.89 P = NS
| | | | Receptive One-Word Picture Vocabulary test (age adjusted), mean ± SD: G2: 41.65 ± 30.46 P = NS GARS Communication Scale, mean ± SD: G2: 16.88 ± 6.48 P = NS Adaptive behavior: GARS Behavior Scale, mean ± SD: G2: 15.82 ± 7.74 P = NS Social skills: GARS Socialization Scale, mean ± SD: G2: 17.18 ± 7.76 P = NS Harms: Parent report of sporadic hyperactivity Modifiers: NR

Delong et al., 2002

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Delong et al., 2002 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: Agency:NR Author industry relationship disclosures: NR Design: Retrospective case series | Intervention: Fluoxetine (0.15 to 0.5 mg/kg) for 5–76 months with discontinuation trials Optimal dose was 4 to 8 mg/day or 15–40 mg/day Assessments: Family histories obtained using family history method in repeated interviews; diagnosis validated by CARS performed by TEACCH or research team & ADOS Groups: G1a: Good/excellent responders G1b: Poor/fair responders Co-interventions held stable during treatment: NR Frequency of contact during study: trials discontinued after 1 year for a period ranging from 4 days to several months among those with excellent/good response Concomitant therapies: NR N at enrollment: 155 N at follow-up: 129 | Inclusion criteria:; - Children 2–8 years old; - CARS scores > 30; Exclusion criteria:; - Neurological/chromosomal disorders; - Severe global impairment; Age, mean/yrs (range): 4.6 (2.83–7.5) Mental age: NR Gender: M: NR F: NR Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In study Diagnostic tool/method: Autism Diagnostic Observation Schedule (ADOS) & validated by CARS Diagnostic category, n (%): Autism: 129 (100) Other characteristics: History of regression, n/N (%): G1a: 64/83 (77) G1b: 22/36 (61) P = 0.12 Family hx of MAD + family hx of BPD, n/N (%): G1a: 32/83 (38.6) | NR | Responders: Fluoxetine response, n (%): Excellent: 22 (17) Good: 67 (52) Fair/poor: 40 (31) Fluoxetine response by family history of major affective disorder, n/N (%): Excellent/good : 67/70 (85) Poor/fair: 19/38 (50) P < 0.001 Fluoxetine response by family history of unusual achievement, n/N (%): With FH: 76/147 (52) Excellent/good response: 52/76 (68) Poor/fair response: 16/76 (21) Without FH: 71/147 (48) Excellent/good response: 21/71 (30) Poor/fair response: 34/71 (48) P < 0.001 Family history of unusual achievement with or without major affective disorder, n/N (%): Families with unusual achievement & major affective disorder: 69/76 (91) Families without unusual achievement & major affective disorder: 37/71 (52) P < 0.001
| | Regression of language & social skills at the onset of recognition of autism, n/N (%): G1a: 56/67 (83.6) Verbal ability, n: G1a: 86 G1b: 38 Some verbal ability, n/N (%): G1a: 66 (77) G1b: 20/38 (52.6) No verbal ability, n: G1a: 20 Hyperlexia, n (%): G1a: 24 (27) G1b: 1 | | Family history of unusual achievement with or without family history of bipolar disorder, n/N (%): Families with unusual achievement & bipolar disorder: 42/76 (55) Families without unusual achievement: 4/71 (6) P < 0.001 Status of children treated for >36 months, n/N: Clinical regression: 18/30 Educational placement, n/N: Regular: 14/30 With other autism children: 5/30 Home school: 3/30 Special classes: 3/30 With Bipolar disorder: 5 males/30 (3 in regular class, 1 in learning disability class, 1 clearly autistic) >3 years treatment with Fluoxetine: 5 Other treatment agents: Lithium : 4 Valproate: 1 (3 discontinued Fluoxetine) Harms : Incidence of diarrhea/rash: 1 Mania: 1
| | | | Modifiers: Treatment response did not correlate with age at starting treatment (data NR)

Drew et al., 2002

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Drew et al., 2002 Country: UK Practice setting: Academic Intervention setting: Hospital clinic Enrollment period: NR Funding: Agency: Medical research council Project grant & from the Special Trustees of Guy’s Hospital Author industry relationship disclosures: NR Design: RCT | Intervention: Parent-training components included behavior management strategies, development of social and communicative competence, play skills, holistic learning, and integration into the routine. Local services group included speech and language therapy, portage home worker input and other paramedical therapy services (OT), ABA: Lovaas Follow up conducted 12 months later (mean age=35 months) Assessments: Research team administered at baseline and follow-up: MCDI, Griffiths Scale of Infant Development, & ADI-R Groups: G1: Parent training G2: Local services Frequency of contact: Hrs/week, mean ± SD: G1: 6.3 ± 10.7 G2: 3.5 ± 3.6 Provider: Research team Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies, n (%): G2: 3 in intensive home-based behavioral program Hrs/week of Other interventions: G1: 0.3 ± 0.1 G2: 8.4 ± 14.9 F(1,23) = 3.6, P = 0.07 | Inclusion criteria: Failure of all 6 items of Shortened version of the CHAT ICD-10 criteria for childhood autism Exclusion criteria: General developmental delay Age, mean/months ± SD: G1: 21.4 ± 2.7 G2: 23.6 ± 3.8 Mental age: NR Gender, n (%): G1: M: 11(91.7) F: 1 (8.3) G2: M: 8 (66.7) F: 4 (33.3) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In study Diagnostic tool/method: CHAT –for screening ADI-R & structures child-adult interaction assessment ICD-10 Structured clinical interview Diagnostic category, n (%): Autism/PDD-NOS: 24 (100) Other characteristics: Hrs/wk spent in playgroup/nursery, mean ± SD: G1: 6.3 ± 10.7 G2: 3.5 ± 3.6 P = NS | Educational/cognitive/academic attainment: Non-Verbal IQ, mean ± SD: G1: 88.1 ± 11.2 G2: 66.0 ± 16.5 NVIQ significantly different between G1 & G2 (P < 0.001) Communication/language: Words understood, mean ± SD: G1: 52 ± 60.5 G2: 53.0 ± 63.7 Words said, mean ± SD: G1: 6.8 ± 20.9 G2: 6.6 ± 13.7 Total gestures produced, mean ± SD: G1: 20.9 ± 7.0 G2: 20.9 ± 14.4 ADI-Non-Verbal Communication, mean ± SD: G1: 12.8 ± 1.6 G2: 12 ± 2.4 ADI overall language rating, n: G1: Nonverbal (< 5 words): 11 Single words: 1 Phrase speech: 0 G2: Nonverbal (<5 words): 11 Single words: 1 Phrase speech: 0 Social skills: ADI-Reciprocal Social Interaction, mean ± SD: G1: 19.6 ± 3.0 G2: 20.3 ± 4.5 | Educational/cognitive/academic attainment: Non-Verbal IQ, mean ± SD: G1: 77.9 ± 14.8 G2: 66.1 ± 17.1 P = NS Communication/language: Words understood, mean ± SD: G1: 176.1 ± 121.9 G2: 100.3 ± 80.2 P = 0.09 Words said, mean ± SD: G1: 96.6 ± 118.8 G2: 44.0 ± 50.2 P = NS Total gestures produced, mean ± SD: G1: 38.6 ± 12.5 G2: 29.1 ± 18.4 P = NS Words understood & gestures produced both significantly different between the 2 groups (P < 0.05) ADI-Non-Verbal Communication, mean ± SD: G1: 11.0 ± 2.8 G2: 11.9 ± 1.8
| Speech & language therapy services, mean/hrs ± SD: G1: 0.3 ± 0.3 G2: 0.6 ± 1.1 1 to 1 structured activities with child, mean/hrs ± SD: G1: 1 ± 0.7 G2: 1.6 ± 1.1 N at enrollment: G1: 12 G2: 12 N at follow-up: G1: 12 G2: 12 | | Repetitive behavior: ADI-Repetitive & Stereotyped Behavior, mean ± SD: G1: 3.2 ± 1.1 G2: 3.7 ± 1.6 Other: Parenting Stress Inventory, mean ± SD: G1: 113.8 ± 21.7 G2: 110 ± 28.6 | ADI overall language rating, n: G1: Nonverbal (<5 words): 4 Single words: 5 Phrase speech: 3 G2: Nonverbal (<5 words): 9 Single words: 3 Phrase speech: 0 Social skills: ADI-Reciprocal Social Interaction, mean ± SD: G1: 18.3 ± 4.9 G2: 20.1 ± 4.3 Repetitive behavior: ADI-Repetitive & Stereotyped Behavior, mean ± SD: G1: 3.9 ± 1.8 G2: 4.2 ± 2.0 Other: Parenting Stress Inventory, mean ± SD: G1: 104.3 ± 20.0 G2: 112.1 ± 20.1 PSI significantly different at P < 0.01 Harms: NR
| | | | Modifiers: Play group, speech and language therapy, other intervention or parent time spent on 1-to-1 activities were not significantly associated with NVIQ, language measures, symptom severity or parental stress at follow-up

Escalona et al., 2002

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Escalona et al., 2002 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NIH, Johnson & Johnson Author industry relationship disclosures: NR Design: RCT | Intervention: Imitation vs. contingently responsive Four phases, each 3 minutes long:; - Phase 1: still face; - Phase 2: unfamiliar adult imitative or contingently responsive to behaviors of child; - Phase 3: still face; - Phase 4: spontaneous play interaction; Assessments: PEP-R, 3-minute videotaped sessions Groups: G1: imitation G2: contingently responsive Provider: NR Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 10 G2: 10 N at follow-up: G1: 10 G2: 10 | Inclusion criteria:; - Diagnosed with autism; - Nonverbal behavior (unspecified); Exclusion criteria:; - See inclusion criteria; Age, years (range): Total: NR (3–7) Female: 4.8 (NR) Male: 5.5 (NR) Mental age: PEP-R cognitive performance, mean developmental level: G1: 19 G2: 17 G1/G2: P = NS Gender, n : Male: 12 Female: 8 Race/ethnicity, %: White: 41 Hispanic: 27 Black: 23 Other ethnic group: 9 SES: Maternal education: NR Household income: NR Hollingshead Index: 2.7 Diagnostic approach: Referral Diagnostic tool/method: DSM-IV (“children diagnosed with autism by the age of 3 by the school’s experienced clinical psychologist”) Diagnostic category, n (%): Autism: 20 (100) Other characteristics: NR | Overall ratings: CARS score, mean: G1: 38 G2: 37 G1/G2: P = NS Social skills: Time spent looking at adult, %: G1: 7.9 G2: 2.6 Time spent more than 5 feet from adult, %: G1: 91.8 G2: 94.6 Time touching adult with a smooth, light touch (“socially positive way”), %: G1: 0.1 G2: 0 Communication/language: Time spent in silence, %: G1: 85.3 G2: 84.7 Repetitive behavior: Time spend showing motor sterotypies, %: G1: 0.9 G2: 0.6 Motor skills: Time spent in motor activity (running/walking/jumping), %: G1: 6.2 G2: 4.4 PEP-R cognitive verbal score, mean developmental level: G1: 17 G2: 14 G1/G2: P = NS | Social skills: Time spent looking at adult, phase 3, %: G1: 6.0 G2: 5.1 G1/BL: P = NS G2/BL: P < 0.05 G1/G2: P = NS Time spent more than 5 feet from adult, phase 3, %: G1: 69.6 G2: 68.6 G1/BL: P < 0.01 G2/BL: P < 0.01 G1/G2: P = NS Time touching adult with a smooth, light touch (“socially positive way”), phase 3, %: G1: 0.9 G2: 0.2 G1/BL: P < 0.05 G2/BL: P = NS G1/G2: P = NS Communication/language: Time spent in silence, phase 3, %: G1: 81.2 G2: 77.9 G1/BL: P = NS G2/BL: P < 0.05 G1/G2: P = NS Repetitive behavior: Time spend showing motor sterotypies, phase 3, %: G1: 0.9 G2: 1.1 G1/BL: P = NS G2/BL: P < 0.05 G1/G2: P = NS
| | | | Motor skills: Time spent in motor activity (running/walking/jumping), phase 3, %: G1: 2.1 G2: 4.3 G1/BL: P = NS G2/BL: P = NS G1/G2: P < 0.01 Harms: NR Modifiers: NR

Comments:

* Entries in baseline column are for phase 1.

Jarusiewicz, 2002

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Jarusiewicz, 2002 Country: US Practice setting: Specialty treatment center Intervention setting: Clinic Enrollment period: NR Funding Agency: NR Author industry relationship disclosures: 1 of 1 EEG Spectrum International (1) Design: RCT | Intervention: Neurofeedback: 30 minute sessions between 1–3 times per week; all completed 20 or more sessions (mean 36, range: 20–69) Assessments: ATEC and 15-minute free-play videos similar to FEAS were conducted prior to and upon completion of the study; parent interview (not described) Other assessments conducted to determine arousal levels (details NR) Groups: G1: neurofeedback G2: control Provider: NR Measure of treatment fidelity reported: NR Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 20 G2: 20 N at follow-up: G1: 12 G2: 12 | Inclusion criteria:; - Prior diagnosis of autism; Exclusion criteria:; - See inclusion criteria; Age, years (range): G1: 7 (4–13) G2: 7 (4–11) Mental age: NR Gender, n: Male: G1: 11 G2 : 11 Female: G1: 1 G2: 1 Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: Independent diagnosis by physician (as reported by parents) Diagnostic category, n (%): Autism: 40 (100) Other characteristics: NR | Overall ratings: ATEC score, mean (range): ATEC Health: G1: 19 (8–42) G2: 21 (8–36) ATEC Total: G1: 65 (26–109) G2: 63 (29–90) Communication/language: ATEC Speech: G1: 14 (6–25) G2: 12 (4–24) Social skills: ATEC Socialization: G1: 15 (2–25) G2: 15 (2–24) Sensory: ATEC Sensory: G1: 18 (10–25) G2: 15 (4–26) | Overall ratings: ATEC score, mean: ATEC Health: G1: 14 G2: 20 G1/BL: P < 0.015 G2/BL: P = NS ATEC Total: G1: 48 G2: 61 G1/BL: P < 0.001 G2/BL: P = NS Communication/language: ATEC Speech: G1: 10 G2: 12 G1/BL: P < 0.001 G2/BL: P = NS Social skills: ATEC Socialization: G1: 10 G2: 14 G1/BL: P < 0.01 G2/BL: P = NS Sensory: ATEC Sensory: G1: 15 G2: 15 G1/BL: P < 0.001 G2/BL: P = NS Harms: NR Modifiers: NR

Molloy et al., 2002

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Molloy et al., 2002 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NIH Author industry relationship disclosures: NR Design: RCT (double-blind cross-over trial) | Intervention: IV Synthetic Human Secretin (2IU/kg at the first visit, followed by equal volume of saline placebo at week 6); other group in the reverse order Assessments: Participants evaluated on 5 occasions: baseline prior to first infusion, week 3, week 6 prior to cross-over infusion, & weeks 9 and 12; each evaluation took place in same room & included CARS, GARS, & DTVP or selected tests of MPS all administered by a clinical psychologist Parents completed ABC and the Autism Behavior Checklist, which were interpreted by the clinical psychologist; parents were asked about stool patterns at each visit, as well as inter-current illnesses, medical problems and medications, and adverse events Receptive language skills evaluated by team of two speech & language pathologists using PPVT-III & Receptive Language Scale of MSEL Expressive language abilities assessed at each visit using 15-minute videotaped sample of spontaneous language during play with caregiver Clinical lab evaluation obtained before each infusion and at week 12 Groups: G1: secretin first, followed by placebo G2: placebo first, followed by secretin | Inclusion criteria:; - 2–15 years of age; - Autism criteria met as per DSM-IV following a multidisciplinary evaluation; - Diagnosis by developmental pediatrician if from outside this center; Exclusion criteria:; - Chromosomal/genetic disorders; - Structural abnormality on neuroimaging; - Acute or chronic pancreatic disease; - Any medical condition that makes participation unsafe; Age, months ± SD: G1: 83.5 ± 32.4 G2: 80.7 ± 30.7 Mental age: NR Gender, n (%): Male: G1: 17 (89.5) G2: 20 (87) Female: G1: 2 (10) G2: 3 (13) Race/ethnicity, n (%): Caucasian: G1: 15 (79) G2: 17 (74) SES: Maternal education: NR Household income: NR Diagnostic approach: In study Diagnostic tool/method: DSM-IV Diagnostic category, n (%): Autism: 42 (100%) PDD-NOS: NR Aspergers : NR Other characteristics: NR | Overall ratings: CARS score, mean ± SD: G1: 40.2 ± 5 G2: 39.2 ± 5.6 G1/G2: P = NS GARS autism quotient, mean ± SD: G1: 102 ± 7.9 G2: 98.6 ± 9.2 G1/G2: P = NS Communication/language: Merrill-Palmer scale, mean ± SD: G1: 22.1 ± 28.5 G2: 30.1 ± 34.6 G1/G2: P = NS Mullen receptive language score, mean ± SD: G1: 18.3 ± 10.5 G2: 18.5 ± 11.5 G1/G2: P = NS PPVT score, mean ± SD: G1: 10 ± 22.4 G2: 13.3 ± 25.1 G1/G2: P = NS Utterance, mean length ± SD: G1: 1.10 ± 1.09 G2: 1.06 ± 1.04 G1/G2: P = NS Type token ratio, mean ± SD: G1: 0.42 ± 0.41 G2: 0.45 ± 0.41 G1/G2: P = NS | Overall ratings: CARS score, week 12, mean ± SD: G1: 40.2 ± 4.9 G2: 38.6 ± 5 G1/BL: P = NS G1/BL: P = NS G1/G2: P = NS GARS autism quotient week 12, mean ± SD: G1: 98.1 ± 8.4 G2: 94.9 ± 8.3 G1/BL: P = NS G1/BL: P = NS G1/G2: P = NS Communication/language: Merrill-Palmer scale, week 12, mean ± SD: G1: 29.5 ± 39.6 G2: 40.1 ± 34.8 G1/BL: P = NS G1/BL: P = NS G1/G2: P = NS Mullen receptive language score, week 12, mean ± SD: G1: 19.5 ± 10.4 G2: 21.1 ± 11 G1/BL: P = NS G1/BL: P = NS G1/G2: P = NS PPVT score, week 12, mean ± SD: G1: 14.2 ± 24.1 G2: 16.9 ± 27.3 G1/BL: P = NS G1/BL: P = NS G1/G2: P = NS Utterance, week 12, mean length ± SD: G1: 0.82 ± 1.11 G2: 0.94 ± 1.07 G1/BL: P = NS G1/BL: P = NS G1/G2: P = NS
| Co-interventions held stable during treatment: NR Frequency of contact during study: Evaluated at weeks 1, 3, 6, 9, 12 Concomitant therapies: NR N at enrollment: G1: 23 G2: 19 N at follow-up: G1: 23 (one participant did not return for the final visit) G2: 19 | | | Type token ratio, week 12, mean ± SD: G1: 0.22 ± 0.31 G2: 0.31 ± 0.3 G1/BL: P = NS G1/BL: P = NS G1/G2: P = NS Harms, n: Worsening of constipation: 1 Elevated AST levels at the first visit: 6 Transient AST elevation: 5 Elevated amylase/lipase: 3 Modifiers: Age and secretin response (data NR)

Salt et al., 2002

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Salt et al., 2002 Country: Scotland UK Practice setting: Specialty treatment center Intervention setting: Clinic Enrollment period: NR Funding: NHS Author industry relationship disclosures: NR Design: Non-RCT | Intervention: Individualized treatment focusing on social, communicative, play, and adaptive behaviors; 8 hours every two weeks for 11 months Parent training component focusing on behavior management and teaching new skills Assessments: All occurred pre- and post-treatment Parent reports: Standardized stress measure and satisfaction questionnaire Clinician conducted: Bayley Scales of Infant Development – 2^nd^ ed; British Picture Vocabulary Scale; VABS; PVCS; MCDI; Symbolic Play Test – 2^nd^ ed; ESCS; PSI – 3^rd^ ed. Groups: G1: (SCA) intervention G2: Control/other intervention Duration (mean ± SD): Non-SCA intervention (hrs/fortnight): Nursery: G1: 27.58 ± 13.32 G2: 38.7 ± 19.45 Other 1:1 therapy: G1: 2.79 ± 9.06 G2: 2.2 ± 2.28 Provider:; - Therapists including nursery nurses, teachers, OT, PT, SLT; - Parents; Treatment manual followed: NR Defined protocol followed: NR | Inclusion criteria:; - Preschool age range; - Accessible geographical location; - Diagnosis of Autism; - Children not excluded on the basis of developmental delay; Exclusion criteria:; - See inclusion criteria; Age, months ± SD: G1: 42.36 ± 7.16 G2: 37.67 ± 3.08 Mental age, months ± SD: G1: 17 ± 5.51 G2: 20.83 ± 2.32 Gender, n (%): Male: G1: 11 (92) G2: 3 (60) Female: G1: 1 (8) G2: 2 (40) Race/ethnicity, n (%): White: 16 (94) Middle eastern: 1 (6) SES: NR Diagnostic approach: Referral Diagnostic tool/method: ICD-10 (WHO, 1993) diagnosis of childhood autism Diagnostic category, n (%): Autism: 17 (100) Other characteristics, IQ (MA/CA) × 100, mean ± SD: G1: 39.43 ± 13.47 G2: 55.67 ± 6.59 | Social skills: VABS score, mean ± SD: Socialization: G1: 51.83 ± 1.9 G2: 55.0 ± 3.39 Symbolic play test score, mean ± SD: G1: 2.27 ± 3.5 G2: 12.8 ± 4.82 Communication/language: VABS Communication: G1: 51.17 ± 2.79 G2: 54.8 ± 3.11 MCDI, mean ± SD: Words understood: G1: 62.55 ± 44.68 G2: 55.6 ± 42.75 Words produced: G1: 4.73 ± 7.46 G2: 11.6 ± 15.08 PVCS imitation score, mean ± SD: G1: 1.92 ± 2.15 G2: 1.6 ± 0.55 ESCS score, mean ± SD: Joint attention: G1: 5.44 ± 3.17 G2: 6.0 ± 3.39 Requesting behavior: G1: 3.67 ± 2.12 G2: 6.6 ± 5.59 Social interaction: G1: 3.33 ± 2.0 G2: 4.2 ± 2.86 Adaptive behavior: VABS Composite score: G1: 49.5 ± 3.75 G2: 54.6 ± 4.83 VABS Daily living skills: G1: 53.08 ± 6.26 G2: 59.0 ± 3.46 Motor skills: VABS Motor skills: G1: 55.92 ± 11.37 G2: 69.8 ± 10.89 | Social skills: VABS socialization score, mean ± SD: G1: 54.08 ± 2.91 G2: 52.8 ± 2.95 P < 0.05 ESCS symbolic play test score, mean ± SD: G1: 6.91 ± 5.94 G2: 19.6 ± 3.78 P = NS ESCS joint attention score, mean ± SD: G1: 9.11 ± 5.58 G2: 4.6 ± 2.97 P < 0.05 ESCS request behavior score, mean ± SD: G1: 10.33 ± 6.96 G2: 6.2 ± 2.77 P = NS (P < 0.06) ESCS social interaction score, mean ± SD: G1: 5.22 ± 2.73 G2: 3.2 ± 0.84 P < 0.05 Communication/language: VABS communication score, mean ± SD: G1: 46.17 ± 15.07 G2: 50.6 ± 1.82 P = NS MCDI, words understood, mean ± SD: G1: 91.18 ± 68.51 G2: 79.8 ± 50.16 P = NS MCDI, words produced, mean ± SD: G1: 17.82 ± 40.94 G2: 31.20 ± 22.61 P = NS
| Measure of treatment fidelity reported: Yes Measure of reliability reported: Yes Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 14 G2: 6 N at follow-up: G1: 12 G2: 5 | | | PVCS imitation score, mean ± SD: G1: 7.67 ± 5.35 G2: 3.8 ± 0.84 P < 0.05 Adaptive behavior: VABS composite score, mean ± SD: G1: 49.33 ± 7.09 G2: 48.6 ± 2.3 P < 0.05 VABS daily living skills score, mean ± SD: G1: 53.67 ± 9.93 G2: 50.8 ± 2.95 P < 0.05 Motor skills: VABS motor skill score, mean ± SD: G1: 55.92 ± 15.06 G2: 55.66 ± 5.32 P < 0.05 Harms: NR Modifiers: NR

Sofronoff et al., 2002

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Sofronoff et al., 2002 Country: Australia Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: Prospective cohort study Note: see related paper with overlapping participants, Sofronoff 2004 {#814} | Intervention: Parent Management Training (PMT) Workshop: attended a 1-day workshop Individual: Six weekly sessions Both groups followed manual with six components (1 hour each) including psychoeducation, comic strip conversations (Gray, 1994a), social stories (Gray, 1994b), management of behavior problems, management of rigid behaviors, routines, and special interests, and anxiety management Groups: G1: Workshop G2: Individual G3: Wait-list Assessment: ECBI (Eyeberg Child behavior Inventory) Parental self-efficacy Questionnaire Used at 3 time points, pre-intervention (T1), 4 weeks Post (T2) and 3 months follow-up (T3) Provider:; - Clinical psychologist; Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR | Inclusion criteria:; - NR; Exclusion criteria:; - NR; Age, mean/years (range): G1: 8.25 (6–12) Gender: NR Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In Study (method): DSM-IV criteria; diagnosis of Asperger syndrome by pediatrician and psychologist at clinic site Diagnostic category: NR Other characteristics: NR | Child problem behaviors: Number of reported problem behaviors by graphical illustration only Parental self-efficacy, mean ± SD: G1: Combined: 2.89 ± 0.84 G1a: 3.03 ± 0.79 G1b: 2.75 ± 0.88 G2: Combined: 2.79 ± 0.9 G2a: 2.61 ± 0.95 G2b: 2.97 ± 0.83 G3: Combined: 3.23 ± 0.89 G3a: 3.21 ± 1.13 G3b: 3.25 ± 0.62 | Child problem behaviors: Number of reported problem behaviors by graphical illustration only Main effect for Time (F=16.98, P < 0.0001) Significant reduction in problem behaviors between T1 & T2 (P < 0.001) for both G1 & G2 & T1 & T3 (P < 0.002) No significant difference between G1 & G2 Significant time × group interaction (F=8.28, P < 0.001) Parental self-efficacy, mean ± SD: Time 3: G1: Combined: 3.26 ± 0.77 G1a: 3.78 ± 0.42 G1b: 2.94 ± 0.79 G1a & G1b significantly different from T1 (P < 0.05) G2: Combined: 3.47 ± 0.67 G2a: 3.65 ± 0.76 G2b: 3.29 ± 0.58 G1a & G1b significantly different from T1 (P < 0.05) G3: Combined: NR G3a: NR G3b: NR
| N at enrollment: G1a: 17 mothers G1b: 16 fathers G2a: 18 mothers G2b: 18 fathers G3a: 10 mothers G3b: 10 fathers N at follow-up: G1a: 17 mothers G1b: 16 fathers G2a: 18 mothers G2b: 18 fathers G3a: 10 mothers G3b: 10 fathers | | | Harms: NR Modifiers: List reported

Unis et al., 2002

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Unis et al., 2002 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NIH Author industry relationship disclosures: NR Design: RCT (double-blind) | Intervention: Single Infusion of either extracted porcine secretin (2 CU/kg), synthetic porcine secretin (0.4 μg/kg) or an appropriate volume of placebo over 2 minutes Assessments: During 1 week prior to infusion (telephone interview) and 4 weeks after infusion; Secretin Outcome Survey (SOS) and ABC-C at 2 weeks postinfusion and 4 weeks ADOS-G, EOWPVT-R, ABC-C Groups: G1: biologic secretin G2: synthetic secretin G3: placebo Co-interventions held stable during treatment: NR Frequency of contact during study: Telephone interview 1 week after infusion; follow-up assessments 4 weeks after infusion Concomitant therapies: NR N at enrollment: 90 N at follow-up: Total: 85 G1: 26 G2: 26 G3: 33 | Inclusion criteria:; - Aged 3–12 years; - DSM-IV diagnosis of autism or PDD-NOS by a physician or clinical psychologist; Exclusion criteria:; - Previously received secretin; - Any medical condition for which autism was considered symptomatic; - Had comorbid epilepsy; - Receiving psychotropic drug Rx 6 months prior to recruitment; - Known allergies to pork products; - NVIQ < 35; Age, months ± SD: G1: 76.5 ± 25.7 G2: 80.7 ± 29.8 G3: 78.3 ± 24.9 Mental age, non-verbal IQ, months ± SD: Total: 55 ± 13 Gender: NR Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In study Diagnostic tool/method: ADOS-G Diagnostic category, n (%): Autism/PDD-NOS: 85 (100) Aspergers: NR Other characteristics: NR | Communication/language: ADOS communication: score, mean ± SD: G1: 5.6 ± 1.7 G2: 6 ± 1.8 G3: 5.7 ± 2 G1/G2/G3: P = 0.75 MacArthur vocabulary score, mean ± SD: G1: 226.2 ± 242.2 G2: 225.3 ± 229.4 G3: 245.9 ± 228.3 G1/G2/G3: P = 0.93 EOW vocabulary score, mean ± SD: G1: 15.2 ± 19.5 G2: 14.9 ± 17.6 G3: 14.6 ± 15.1 G1/G2/G3: P = 0.99 Social Skills: ADOS social score, mean ± SD: G1: 10 ± 2.0 G2: 9.8 ± 2.3 G3: 9.6 ± 2.1 G1/G2/G3: P = 0.78 Problem behavior: ABC total score, parent-rated, mean ± SD: G1: 61.4 ± 22.1 G2: 54.2 ± 24 G3: 58.9 ± 32 G1/G2/G3: P = 0.63 ABC total score, teacher-rated, mean ± SD: G1: 54.8 ± 22.3 G2: 56.4 ± 24.0 G3: 57.5 ± 20.4 G1/G2/G3: P = 0.90 Medical: SOS score, teacher-rated, mean ± SD: G1: 4.7 ± 1.3 G2: 4.7 ± 1.6 G3: 4.7 ± 1.2 G1/G2/G3: P = 0.99 | Communication/language: ADOS communication score, mean change (95% CI): G1: −0.2 (−0.8, 0.4) G2: −0.2 (−0.8, 0.5) G3: 0.2 (−0.5, 0.8) ANOVA: time & treatment (P = NS) MacArthur vocabulary score, mean change (95% CI): G1: 16.5 (−11.7, 44.8) G2: 12.3 (−5.6, 30.2) G3: 23.4 (9.7, 37.1) ANOVA: time (P < 0.01) treatment (P = NS) EOW vocabulary score, mean change (95% CI): G1: 1.2 (−0.4, 2.9) G2: −0.7 (−2.2, 0.7) G3: 2.1 (0.2, 4.1) ANOVA: time & treatment (P = NS) Social Skills: ADOS social score, mean change (95% CI): G1: 0.0 (−0.9, 0.9) G2: 0.0 (−0.9, 0.9) G3: −0.5 (−1.3, 0.3) ANOVA: time & treatment (P = NS)
Author: Unis et al., 2002 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NIH Author industry relationship disclosures: NR Design: RCT (double-blind) | | | SOS total score, parent-rated, mean ± SD: G1: 4.3 ± 1.5 G2: 4.4 ± 1.5 G3: 4.0 ± 1.9 G1/G2/G3: P = 0.64 | Problem Behavior: ABC total score, parent-rated, mean change (95% CI): G1: −10.6 (−18.9, − 2.3) G2: −5.2 (−10.0, − 0.3) G3: −5.8 (−12.4, 0.9) ANOVA: time (P < 0.001) treatment (P = NS) ABC total score, teacher-rated, mean change (95% CI): G1: 0.4 (−8.3, 9.1) G2: −7.9 (−16.1, 0.3) G3: −12.0 (−18.2, − 5.7) ANOVA: time (P < 0.01) treatment (P < 0.05) Medical: SOS total score, parent-rated, mean change (95% CI): G1: −0.5 (−0.9, − 0.1) G2: −0.7 (−1.0, − 0.4) G3: −0.5 (−0.9, − 0.1) ANOVA: time (P < 0.001) treatment (P = NS)
Author: Unis et al., 2002 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NIH Author industry relationship disclosures: NR Design: RCT (double-blind) | | | | SOS total score, teacher-rated, mean change (95% CI): G1: −0.2 (−1.0, 0.7) G2: −0.5 (−1.1, 0.0) G3: −0.6 (−1.3, 0.1) ANOVA: time (P < 0.05) treatment (P = NS) Harms: 1 child developed fever and illness after the infusion; protocol was completed, but data not included in the analyses Modifiers: Analyses using subgroups (Vineland communication scores < 60, children age < 72 months, those with & without GI problems) were similar to the original sample analyses No evidence of secretin efficacy. No significant treatment effect was noticed for subgroups as defined below. SG1: Vineland communication < 60 SG2: Age < 72 months SG3: Current GI problems SG4: No current GI problems

## 2001

Carmody et al., 2001

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Carmody et al., 2001 Country: Hong Kong Practice setting: Academic Intervention setting: Child development center Enrollment period: July 1994 to December 1995 Funding: Portion sponsored by NYU Author industry relationship disclosures: NR Design: Case series | Intervention: 2 sets of eyeglasses with prism lenses (5 diopters), 1 with lenses oriented prism base-up and the other oriented prism base- down All children assessed without glasses (habitual viewing) and with each of the two study eyeglasses (base-up viewing and base-down viewing) Base-up, base-down ambient lenses trials for 60–90 seconds/trial with a random order of lenses Facilitating lenses: the prism eyeglasses that worked best for an individual patient Assessment: Each participant assessed independently by one experimenter in a single session lasting 20–30 minutes. Behavior assessment done by raters, performance videotaped Groups: G1: all participants Provider: Optometrist or pediatrician Treatment manual followed: No Defined protocol followed: Yes Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NA | Inclusion criteria:; - Children consecutively referred to a child development center and diagnosed with autistic disorder by DSM-IV or WHO criteria; Exclusion criteria:; - See inclusion criteria; Age, median years (range): 8 (3–18) Mental age: NR Gender, n (%): M: 22 (91.7) F: 2 (8.3) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Referral Diagnostic tool/method: DSM-IV, WHO criteria Diagnostic category, n (%): Autistic disorder: 24 (100) Other characteristics, n: Normal visual acuity: 18 Far-sighted: 3 Near-sighted: 3 | Motor skills: Ball catch score, mean % ± SD: Habitual viewing: 31.30 ± 22.53 Ball misses, %: Habitual viewing: 49 Ball passive catches (ball caught after rebounding off child’s body), %: Habitual viewing: 31 Ball active catches (ball caught on swing without hitting child first), %: Habitual viewing: 20 | Motor skills: Ball catch score, mean % ± SD: Facilitating lenses: 70.91 ± 24.94 Habitual vs. Facilitating lenses, t(22) = 7.656, P < 0.0001 Ball misses, %: Facilitating lenses: 24 Ball passive catches (ball caught after rebounding off child’s body), %: Facilitating lenses: 12 Ball active catches (ball caught on swing without hitting child first), %: Facilitating lenses: 64 Children’s ability to catch a ball was significantly better with use of facilitating lenses as compared with habitual viewing (P < 0.0001) Harms NR Modifiers NR
| Concomitant therapies: NR N at enrollment: G1: 24 N at follow-up: G1: 24

Coniglio et al., 2001

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Coniglio et al., 2001 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: Children’s Healthcare of Atlanta Foundation Author industry relationship disclosures: NR Design: RCT (method of randomization not described) | Intervention: Porcine secretin administered IV (test dose of 0.1 ml; if no acute anaphylactic reaction in 1 minute, 2.0 CU/kg (maximum of 75 CU) administered over 1 minute) Assessments: 1 pre-injection and 2 post- injection developmental/behavioral assessments: Presence or absence of normal development in early infancy and any associated gastro-intestinal disturbances Performed by 4 evaluators (2 clinical psychologists, 1 advanced psychology graduate student, 1 developmental pediatrician) Groups: G1: secretin G2: placebo (saline) Co-interventions held stable during treatment: No; approximately 7% of parents indicated that they had started a new treatment regimen since beginning the study Frequency of contact during study: At screening and injection, and at 3 and 6 weeks post-injection Concomitant therapies: NR N at enrollment: G1: 30 G2: 30 N at follow-up: G1: 28 G2: 29 | Inclusion criteria:; - Met DSM-IV criteria for diagnosis of autism; - CARS score ≥ 30; - Total PLS-3 ≤ 60 months; Exclusion criteria:; - See inclusion criteria; Age, months ± SD: G1: 84.6 ± 25.2 G2: 83.5 ± 28.9 Mental age: NR Gender, %: Male: G1: 73 G2: 77 Female: G1: 23 G2: 27 Race/ethnicity, %: White: G1: 80 G2: 77 African American: G1: 17 G2: 13 Other: G1: 3 G2: 10 SES: Maternal education: NR Household income: NR Diagnostic approach: In Study Diagnostic tool/method: DSM-IV criteria were assessed for each child to provide documentation of the diagnosis of autism before study entry Diagnostic category, %: Autism: G1: 50 G2: 52 PDD: G1: 24 G2: 14 | Overall ratings: CARS total score, mean ± SD: G1: 42.4 ± 5.4 G2: 41.3 ± 6.3 GARS autism quotient, mean ± SD: G1: 104.1 ± 15.4 G2: 108.1 ± 11.9 PLS total age, months ± SD: G1: 15.4 ± 9.5 G2: 22.0 ± 12.8 | Overall ratings: CARS total score, 3 weeks, mean ± SD: G1: 39.2 ± NR G2: 41.9 ± NR G1/BL: P = 0.051 CARS total score, 6 weeks, mean ± SD: G1: 41.8 ± NR G2: 41.7 ± NR ANOVA: time & treatment (P = NS) Improvement in CARS total scores BL to 6 weeks, %: G1: 36 G2: 28 G1/G2: P = NS GARS autism quotient, 3 weeks, mean ± SD: G1: 92 ± NR G2: 99 ± NR GARS autism quotient, 6 weeks, mean ± SD: G1: 92 ± NR G2: 99 ± NR ANOVA: time (P = 0.000) treatment (P = NS) PLS total age, 3 weeks, months ± SD: G1: 16 ± NR G2: 21 ± NR PLS total age, 6 weeks, months ± SD: G1: 17 ± NR G2: 21 ± NR ANOVA: time & treatment (P = NS)
| | Autism and PDD: G1: 24 G2: 36 Aspergers: G1: 0 G2: 0 Other characteristics: DSM-IV diagnostic characteristics, %: Impairment in nonverbal behaviors: G1: 97 G2: 100 Failure to develop peer relationships: G1: 97 G2: 100 Lack of spontaneous relationships with others: G1: 52 G2: 75 Lack of social or emotional reciprocity: G1: 48 G2: 71 Delay in or total lack of spoken language: G1: 97 G2: 82 In those without severe language impairment, inability to initiate or sustain conversation with others: G1: 55 G2: 50 Stereotyped or repetitive use of language: G1: 43 G2: 57 Lack of spontaneous make-believe or social play: G1: 72 G2: 75 Preoccupation with one or more stereotypes: G1: 83 G2: 89 Inflexible adherence to routines or rituals: G1: 48 G2: 57 | | Social skills: Parent reported changes in social behavior or language, %: G1: 67 G2: 42 Medical: Parent-reported changes in GI symptoms, %: 26 Formed stools at enrollment, %: Subjects who displayed sustained change: 89 Subjects who did not display sustained change: 42 (P = 0.02) No differences in average stools/day or presence of blood in stools were noted Harms: Parents observed side effects since injection (transient irritability; hyperactivity; nausea/vomiting), %: 13 Modifiers: Correlation of PLS and CARS score: Baseline: −0.57 (P < 0.000) 3 weeks: −0.44 (P < 0.001) 6 weeks: −0.3 (P < 0.004) No significant correlation between PLS and GARS
| | Stereotyped and repetitive motor mannerisms: G1: 83 G2: 79 Persistent preoccupation with parts of objects: G1: 55 G2: 54 Delay in social interaction: G1: 90 G2: 93 Delay in language: G1: 100 G2: 93 Delay in symbolic or imaginative play: G1: 90 G2: 82 Height, inches ± SD: G1: 45.8 ±7.2 G2: 46.5 ±7.5 Weight, kg ± SD: G1: 27.8 ±12.3 G2: 26.6 ±11.2 Age at symptom onset, months ± SD: G1: 18.2 ± 8.5 G2: 20.1 ± 8.5 Age at first diagnosis, months ± SD: G1: 33.1 ± 10.2 G2: 33.7 ± 10.1 Initial normal development, %: G1: 62 G2: 90 G1/G2: P = 0.014 Average stools/day, %: 0–1: G1: 40 G2: 33 1–2: G1: 30 G2: 37 2–4: G1: 20 G2: 20 > 4: G1: 10 G2: 10
| | Stool consistency, %: Watery: G1: 0 G2: 10 Applesauce: G1: 40 G2: 30 Formed: G1: 60 G2: 60 Blood in stools, %: Never: G1: 97 G2: 93 Once/month: G1: 3 G2: 7

Escalona et al., 2001

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Escalona et al., 2001 Country: US Practice setting: Academic Intervention setting: home Enrollment period: NR Funding: NIH, Johnson & Johnson Author industry relationship disclosures: NR Design: RCT | Intervention: massage therapy provided by parents for 15 minutes just prior to bedtime every night for 1 month. Parents were trained by massage therapists. Parents of the attention control group read Dr. Seuss stories on the same time schedule to their children Groups: G1: massage therapy administered by parents G2: reading attention control group Assessments: Revised Conners Scales Classroom and playground behavior observations Sleep diaries Co-interventions held stable during treatment: NR Frequency of contact during study: Assessments on 1^st^ and last days of study; intervention/control activities occurred daily with parents Concomitant therapies: NR N at enrollment: G1+G2: 20 N at follow-up: G1+G2: 20 | Inclusion criteria:; - Children with autism recruited from a school for children with autism; - Ages 3–6 years; Exclusion criteria:; - See inclusion criteria; Age, mean/yrs ± SD: 5.2 ± 1.8 Mental age: NR Gender: M, n (%): 12 (60) F, n (%): 8 (40) Race/ethnicity, %: White: 72 Hispanic: 20 African American: 8 SES: Middle socioeconomic status: Hollingshead Index, mean: G1 & G2: 1.8 Diagnostic approach: Children had been diagnosed by 2 independent clinicians ~1–3 years earlier using DSM III-R criteria. Diagnostic tool/method: DSM-III-R Diagnostic category, n (%): Autism: 20(100) Other characteristics: NR | Revised Conners Scales, mean: ADHD Index, parent rating: G1: 66 G2: 65 Restless-impulsive behaviors, parent rating: G1: 66 G2: 66 Emotional index, teacher rating: G1: 62 G2: 62 Emotional index, parent rating: G1: 58 G2: 55 Global index DSM-IV scale for inattentiveness, teacher rating: G1: 56 G2: 60 DSM-IV scale for inattentiveness, parent rating: G1: 62 G2: 56 Classroom/playground, frequency of behaviors, %: On-task behavior, classroom: G1: 81 G2: 81 Stereotypical behavior, classroom: G1: 8 G2: 5 Stereotypical behavior, playground: G1: 13 G2: 12 Social relatedness to teacher, playground: G1: 14 G2: 14 | Revised Conners Scales, mean: ADHD Index, parent rating: G1: 60 G2: 64 t = 1.91, (P < 0.05) Restless-impulsive behaviors, parent rating: G1: 60 G2: 63 t = 2.05, (P < 0.05) Emotional index, teacher rating: G1: 55 G2: 60 t = 1.83, (P < 0.05) Emotional index, parent rating: G1: 54 G2: 55 t = 2.11, (P < 0.05) Global index DSM-IV scale for inattentiveness, teacher rating: G1: 50 G2: 62 t = 1.75, (P < 0.05) DSM-IV scale for inattentiveness, parent rating: G1: 63 G2: 61 t = 1.97, (P < 0.05) Classroom/playground, frequency of behaviors, %: On-task behavior, classroom: G1: 94 G2: 91 t = 2.13, (P < 0.05)
| | | | Stereotypical behavior, classroom: G1: <1 G2: 2 t = 2.01, (P < 0.05) Stereotypical behavior, playground: G1: 2 G2: 8 t = 3.29, (P < 0.01) Social relatedness to teacher, playground: G1: 20 G2: 11 t = 2.04, (P < 0.05) Sleep diaries Measures not provided, described as indicating greater declines for massage group on fussing/restlessness, crying, self-stimulating behavior, and getting out of bed. Teachers Conners Scales: Significant Group × Days interaction effect (F(5,14)=3.08, P < 0.05) Observation behaviors: Significant group × days interaction effect (F(6,13)=2.98, P < 0.05) Harms: NR Modifiers: NR

Comments:

* Results in baseline section are behaviors during spontaneous play in the first session (not a true baseline as the probe occurred after the first intervention had begun).

Hartshorn et al., 2001

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Hartshorn et al., 2001 Country: US Practice setting: Academic Intervention setting: School for children with autism Enrollment period: NR Funding: NIH, Johnson and Johnson Author industry relationship disclosures: NR Design: Non randomized controlled trial | Intervention: 30 minute movement sessions held twice a week for two months Controls matched on age and developmental level Assessments: Behavior coded in 10-second time sample units for 6 one-minute periods during the first 18 minutes of first and last sessions; controls observed during two sessions two months apart Groups: G1: intervention G2: controls Provider:; - Sessions given by trained movement therapists.; - Behaviors observed and coded by psychology graduate students with prior training to 80% reliability; Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 38 G2: 38 N at follow-up: G1: 38 G2: 38 | Inclusion criteria:; - From a school for children with autism; - Control group matched on age and development level with movement therapy group (from same school); Exclusion criteria:; - See inclusion criteria; Age, years (range): G1: 5 (3–7) G2: NR Mental age: NR Gender: NR Race/ethnicity, %:^*^ White: G1: 80 Hispanic: G1: 10 Black: G1: 10 SES: Maternal education: NR Household income:^*^ G1: “Middle SES” Diagnostic approach: In Study/Referral Diagnostic tool/method: NR Diagnostic category: See inclusion criteria Other characteristics: NR | Percentage of time behavior observed in session, mean ± SD: Adaptive behavior: Stereotypical behaviors: G1: 2.0 ± 0.5 G2: 3.0 ± 0.4 Wandering: G1: 14.0 ± 2.4 G2: 16.0 ± 2.8 Social skills: Responding to touch negatively: G1: 5.0 ± 8 G2: 4.0 ± 0.9 On-task passive: G1: 16.0 ± 4.3 G2: 15.0 ± 5.9 On-task active: G1: 77.0 ± 15.6 G2: 9.0 ± 13.2 Eye contact: G1: 9.0 ± 2.5 G2: 11.0 ± 3.1 Social relatedness toward teacher: G1: 28.0 ± 9.3 G2: 25.0 ± 11.2 Resisting teacher: G1: 9.0 ± 1.7 G2: 12.0 ± 1.5 | Percentage of time behavior observed in session, mean ± SD: Adaptive behavior: Stereotypical behaviors: G1: 2.0 ± 0.7 G2: 4.0 ± 1.2 G1/G2: P = NS Wandering: G1: 10.0 ± 3.1 G2: 15.0 ± 2.9 G1/G2: P < 0.05 Social skills: Responding to touch negatively: G1: 1.0 ± 2 G2: 3.0 ± 0.5 G1/G2: P < 0.01^**^ On-task passive: G1: 37.0 ± 116 G2: 19.0 ± 7.3 G1/G2: P < 0.001^**^ On-task active: G1: 76.0 ± 19.1 G2: 67.0 ± 16.3 G1/G2: P = NS Eye contact: G1: 7.0 ± 1.9 G2: 9.0 ± 2.4 G1/G2: P = NS Social relatedness toward teacher: G1: 25.0 ± 7.9 G2: 21.0 ± 8.3 G1/G2: P = NS Resisting teacher: G1: 4.0 ± 1.5 G2: 10.0 ± 1.3 G1/G2: P < 0.05^**^ Harms: NR Modifiers: NR

Comments:

* This measure for G2 is described as “similar” to G1 but otherwise not reported.

** The p-values for three behaviors were different in the table (reported above) and the text: responding to touch negatively (text P < 0.005; table P < 0.01), on-task passive (text P < 0.05; table P < 0.001), and resisting teacher (text: P < 0.01; table: P < 0.05).

Kern et al., 2001

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Kern et al., 2001 Country: US Practice setting: Community Intervention setting: Clinic Enrollment period: NR Funding: FoodScience Corporation Author industry relationship disclosures: NR Design: Double-blind, randomized controlled trial | Intervention: Oral dimethylglycine, 125 mg/day (placebo group received mannitol tablets of the same size and frequency) Titration by weight: < 40 lbs: 1 tablet 41–70 lbs: 2 tablets 71–100 lbs: 3 tablets 101–130 lbs: 4 tablets > 131 lbs: 5 tablets Assessments: Neurological and behavioral assessments performed in childcare room at University of Dallas with toys and activity centers; a variety of items were available to use during the behavioral observations, such as wooden blocks, crayons, pencils, paper, and balls; parents were present Behavioral: VABS maladaptive behavior domain, ABC subscales I-V; obtained at baseline and 4 weeks post treatment; videotaped Neurologic: examination of coordination, posturing, toe walking Groups: G1: dimethylglycine G2: placebo Co-interventions held stable during treatment, n: Yes Frequency of contact during study: Participants met with investigators at baseline and 4 weeks after treatment began | Inclusion criteria:; - Met the DSM-IV diagnostic criteria for autism or PDD; Exclusion criteria:; - See inclusion criteria; Age, years (range): NR (3–11) Mental age: NR Gender: NR Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In Study Diagnostic tool/method: DSM-IV Diagnostic category, n (%): Autistic or PDD-NOS: 37 (100) Other characteristics, n (%): Gross/fine motor skill delay: 26 (70) Problems with gross/fine ocular pursuit: 4 (11) Poor muscle tone: 5 (14) Non-verbal: 10 (27) Echolalic: 12 (32) Difficulty sleeping: 16 (43) Eating disorders: 16 (43) Hyperlexia: 4 (11) | Problem behavior: VABS maladaptive behavior score, mean: G1: NR G2: NR G1/G2: P < 0.35 ABC irritability and self-abusive behavior score, mean: G1: NR G2: NR G1/G2: P < 0.46 Social skills: ABC lethargy, social withdrawal, and withdrawal score, mean: G1: NR G2: NR G1/G2: P < 0.0003 Repetitive behavior: ABC stereotypic behavior score, mean: G1: NR G2: NR G1/G2: P < 0.58 ABC hyperactivity score, mean: G1: NR G2: NR G1/G2: P < 0.35 Communication/language: ABC inappropriate speech score, mean: G1: NR G2: NR G1/G2: P < 0.84 Neurologic assessments: Standard neurological exam, n: G1: 17 G2: 16 | Overall ratings: Main behavioral effect change, mean (range across all assessment methods): G1: 0.71 (0.06, 1.94) G2: 0.87 (0.32, 1.68) G1/G2: P = NS Parent report of treatment effect, n (%): Positive response: G1: 11 (58) G2: 10 (53) Negative response: G1: 3 (16) G2: 6 (32) No response: G1: 5 (26) G2: 3(16) Social skills: ABC lethargy, social withdrawal, and withdrawal score, mean change (%improvement): G1: 1.94 (15.3) G2: 0.95 (13.6) G1/G2: P < 0.12 Communication/language: ABC inappropriate speech score, mean change: G1: NR G2: NR G1/G2: P = NS Repetitive behavior: ABC stereotypic behavior score, mean change: G1: NR G2: NR G1/G2: P = NS
| Concomitant therapies: Psychoactive medication (clonidine, thioridazine, paroxetine, imipramine, methylphenidate, & fluoxetine): 7 N at enrollment: G1: 20 G2: 19 N at follow-up: G1: 18 G2: 19 | | | ABC hyperactivity score, mean change: G1: NR G2: NR G1/G2: P = NS Problem behavior: VABS maladaptive behavior score, mean change: G1: NR G2: NR G1/G2: P = NS ABC irritability and self-abusive behavior score, mean change: G1: NR G2: NR G1/G2: P = NS Motor skills: Improved gross motor function, neurologic assessment, n: G1: 3/17 G2: 0/16 G1/G2: P = 0.57 Harms, n (%): Hyperactivity: G1: 2 (11) G2: 4 (21) Increased aggression: G1: 1 (5) G2: 2 (11) Difficulty sleeping: G1: 1 (5) G2: 2 (11) Any negative effects, %: G1: 16 G2: 32 Withdrawn due to adverse behavioral changes, n: Total: 1 Modifiers: NR

King et al., 2001

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: King et al., 2001 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: Cerebrus PLC Author industry relationship disclosures: NR Design: Multi-center, Double-blind, randomized, placebo controlled trial | Intervention: Week 1 (run-in): 2.5mg/kg/day placebo given to both groups Week 2: amantadine chloride or placebo given 2.5mg/day at breakfast Week 3–5: amantadine chloride or placebo given 2.5mg/kg 2 times per day at breakfast and afternoon Assessments: Visit 0: screen (subject screening and recruitment) Visit 1: baseline, end of 1-week placebo run-in (at end of week 1, subject’s compliance and ABC-C was assessed) Visits 2,3,4,&5: treatment ABC-C (parent or care provider completed instrument at visits 0, 1, & 2–5 inclusive; ADOS-G (videotaped and at visits 0 & 5); CGI (visit 1 and visits 2–5 inclusive) Groups: G1: amantadine chloride G2: placebo control Co-interventions held stable during treatment, n (%): Patients on SSRI’s stable for >1month remained on medication G1: 4 (20) G2: 6 (30) Frequency of contact during study: Every week Concomitant therapies: SSRI: G1: 4/19 G2: 6/20 N at enrollment: G1: 19 G2: 20 | Inclusion criteria:; - Diagnosis of autism by DSM-IV and ICD-10 criteria using ADI-R and ADOS-G; - ABC-CV subscales for irritability (subscale I) and hyperactivity (subscale IV) were > age adjusted 75 percentile; - VABS age equivalent > 18 mos; Exclusion criteria:; - IQ score <35 on Mullen Scales or Differential Ability scale; - Presence of Fragile X and tuberous sclerosis complex; - Receiving neuroleptic, anticonvulsant, or stimulant medication; - Evidence of clinically evident medical illness; Age, mean/yrs (range): G1: 7 (5–11) G2: 7 (5–15) Mental age: NR Gender, n (%): M: G1: 15 (80) G2: 19 (95) F: G1: 4 (20) G2: 1 (5) Race/ethnicity, n (%): White: G1: 15(79) G2: 15 (75) Other: G1: 4 (21) G2: 5 (25) SES: Maternal education: NR Household income: NR Diagnostic approach: In Study | Problem behavior: ABC-irritability, mean (range): G1: 19.1 (3–38) G2: 18.7 (3–33) Commonly occurring comorbidities: ABC-hyperactivity, mean (range): G1: 29.4 (16–42) G2: 32.7 (17–46) | Overall ratings: CGI-rate illness severity, (success rate %): G1: 53 G2: 25 P = 0.076 Communication/language: ABC-inappropriate speech, mean change (95% CI): Provider: −2.24 (−3.85 to −0.63) Repetitive behavior: ABC-stereotyped behavior, mean change (95% CI): Provider: −2.20 (−4.74 to 0.33) Problem behavior ABC-irritability (parent-rated), mean change (95% CI): Parent : G1: NR G2: NR P = 0.178 Commonly occurring co-morbidities: ABC-hyperactivity (parent-rated), mean change (95% CI): Parent : G1: −4.9 G2: −1.6 Total: −4.81 (−11.63 to 2.00) Care provider: −5.75 (−11.39 to − 0.1)
| N at follow-up: G1: 19 G2: 20 | Diagnostic tool/method: DSM-IV, ICD-9, ABC-CV, ADOS-G, ADI-R Diagnostic category, n (%): Autism 39 (100) Other characteristics: CGI-rate illness severity, n (% NR): Mild: G1: 0 G2: 1 Moderate: G1: 11 G2: 11 Severe: G1: 8 G2: 7 | | Harms, n (%): Insomnia: G1: 4 (21) G2: 2 (10) Somnolence: G1: 2 (11) Antisocial behaviors: G1: 2 (11) G2: 4 (20) Modifiers: NR

Owley et al., 2001

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Owley et al., 2001 Country: US Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: UC Davis MIND Institute, NIH, Jean Young and Walden Shaw Foundation, Irving Harris Foundation Author industry relationship disclosures: NR Design: Multisite double-blind, parallel group RCT crossover design | Intervention: Porcine secretin or saline placebo 2 CU/kg infused at baseline or end of week 4, injected over 1 minute Assessment: DAS; MSEL for children under 5 and those for which a basal could not be established on subtests of the DAS; DTVP-II, ADOS, PPVT-III (> 5 years and able to establish basal) VABS Interview Edition and CGI scales at baseline and end of weeks 4 and 8, GARS and ABC-C at baseline and end of weeks 2, 4, 6, and 8 Groups: G1: secretin first, followed by placebo G2: placebo first, followed by secretin Co-interventions held stable during treatment: Yes Frequency of contact during study: Baseline and assessments at week 4 (primary outcome) and week 8 (crossover assessment) Concomitant therapies, n: SSRI: 3 Atypical neuroleptics: 3 Alpha adrenergic agonist: 1 Psychostimulants: 8 N at enrollment: G1: 28 G2: 28 N at follow-up: G1: 28 G2: 28 | Inclusion criteria:; - Diagnosis of autism confirmed in study; - For subjects younger than 5, non verbal ratio IQ > 20 according to Mullen Scales of Early Learning; - For subjects with non verbal IQ 20–34, VABS age equivalent of ≥ 24 months; Exclusion criteria:; - History of allergy to porcine products; - Significant history of illness including nonfebrile seizures and excluding autism; Age, months ± SD: G1: 79.6 ± 21.8 G2: 81.4 ± 24.4 Mental age: Non-verbal IQ, mean ± SD: G1: 55.9 ± 24.5 G2: 56.9 ± 19.4 Gender, n (%): Male: G1: 24 (85.7) G2: 24 (85.7) Female: G1: 4 (14.3) G2: 4 (14.3) Race/ethnicity, n (%): African American: G1: 1 (3.6) G2: 3 (10.7) Hispanic: G1: 2 (7.1) G2: 4 (14.3) Asian: G1: 1 (3.6) G2: 0 White: G1: 24 (85.7) G2: 21 (75) SES: Maternal education: NR Household income: NR Diagnostic approach: In Study | Overall ratings: CGI-S score, mean ± SD: G1: 3.0 ± 0.8 G2: 2.8 ± 0.8 GARS autism quotient, mean ± SD: G1: 93.6 ± 12.0 (n=26) G2: 86.5 ± 11.7 (n=27) G1/G2: P = 0.03 Social skills: ADOS social interaction score, mean ± SD: G1: 11.9 ± 1.5 G2: 10.8 ± 1.9 G1/G2: P < 0.018 GARS social interaction score, mean ± SD: G1: 8.4 ± 2.4 (n=26) G2: 6.9 ± 2.2 (n=27) G1/G2: P = 0.02 ADOS play score, mean ± SD: G1: 2.6 ± 1.6 G2: 2.2 ± 1.5 Vineland socialization score, mean ± SD: G1: 35.5 ± 18.0 G2: 39.5 ± 19.2 Communication/language: ADOS communication score, mean ± SD: G1: 6.8 ± 1.8 G2: 6.5 ± 2.1 ADOS communication + social interaction scores, mean ± SD: G1: 18.7 ± 3.7 G2: 17.3 ± 3.5 | Overall measures: CGI-S score, week 4, mean ± SD: G1: 2.9 ± 0.8 G2: 2.7 ± 0.9 GARS autism quotient, week 4, mean ± SD: G1: 86.9 ± 13.2 (n=26) G2: 82.5 ± 15.2 Social skills: ADOS social interaction score, week 4, mean ± SD: G1: 11.5 ± 1.5 G2: 10.1 ± 1.8 GARS social interaction score, week 4, mean ± SD: G1: 7.3 ± 2.7 G2: 6.2 ± 2.5 ADOS play score, week 4, mean ± SD: G1: 2.7 ± 1.3 G2: 2.0 ± 1.4 Vineland socialization score, week 4, mean ± SD: G1: 34.6 ± 17.9 G2: 39.3 ± 18.4 Communication/language: ADOS Communication score, wwek 4, mean ± SD: G1: 6.5 ± 1.7 G2: 6.3 ± 2.2 ADOS communication + social interaction scores, week 4, mean ± SD: G1: 18.1 ± 2.5 G2: 16.4 ± 3.5 GARS communication score, week 4, mean ± SD: G1: 9.2 ± 3.0 (n=22) G2: 8.0 ± 3.3
| | Diagnostic tool/method: ADI-R, ADOS confirmed with DSM-IV diagnosis Diagnostic category, n (%): Autistic disorder: G1: 28 (100) G2: 28 (100) Other characteristics: ADI score, mean ± SD: Social interaction: G1: 23.4 ± 3.6 G2: 23.0 ± 4.5 Communication verbal: G1: 13.5 ± 3.8 (n=21) G2: 13.3 ± 3.4 (n=23) Communication-nonverbal: G1: 18.7 ± 2.1 (n=7) G2: 15.6 ± 3.5 (n=5) Repetitive behavior: G1: 6.0±2.5 G2: 5.4±1.9 Abnormality of development: G1: 4.3 ± 0.7 G2: 4.1 ± 0.9 | GARS communication score, mean ± SD: G1: 9.5 ± 2.7 (n=22) G2: 8.5 ± 2.4 (n=27) Mullen/DAS/PPVT/DTVP-2 receptive language score, months ± SD: G1: 29.0 ± 23.8 G2: 37.4 ± 28.9 Mullen/DAS/PPVT/DTVP-2 fine motor score, months ± SD: G1: 45.9 ± 25.4 G2: 47.5 ± 23.4 Vineland communication score, mean ± SD: G1: 35.9 ± 22.2 G2: 41.7 ± 26.7 Problem behavior: ADOS stereotyped behavior, mean ± SD: G1: 3.6 ± 1.6 G2: 2.5 ± 1.3 G1/G2: P < 0.007 GARS stereotyped behaviors, mean ± SD: G1: 9.4 ± 2.4 (n=26) G2: 8.0 ± 2.7 (n=27) G1/G2: P = 0.049 ABC-C subscale score, mean ± SD: Irritability: G1: 11.6 ± 7.5 (n=27) G2: 10.1 ± 7.1 (n=27) Lethargy: G1: 13.7 ± 7.1 (n=27) G2: 8.3 ± 6.7 (n=27) G1/G2: P = 0.006 Stereotypy: G1: 7.3 ± 4.0 (n=27) G2: 5.1 ± 3.5 (n=27), G1/G2: P = 0.035 | Mullen/DAS/PPVT/DTV P-2 receptive language score, week 4, months ± SD: G1: 29.1 ± 21.8 G2: 40.1 ± 31.6 Mullen/DAS/PPVT/DTV P-2 fine motor score, week 4, months ± SD: G1: 44.6 ± 25.1 (n=27) G2: 45.6 ± 20.8 (n=27) Vineland communication score, week 4, mean ± SD: G1: 38.3 ± 24.7 G2: 41.7 ± 24.9 Problem Behavior: ADOS stereotyped behavior score, week 4, mean ± SD: G1: 3.8 ± 1.5 G2: 3.2 ± 1.8 GARS stereo-typed behaviors score, week 4, mean ± SD: G1: 7.6 ± 3.0 (n=26) G2: 7.1 ± 2.9 ABC-C subscale score, week 4, mean ± SD: Irritability: G1: 10.1 ± 10.2 (n=26) G2: 10.9 ± 8.1 Lethargy: G1: 10.2 ± 5.9 (n=26) G2: 7.8 ± 7.1 Stereotypy: G1: 6.3 ± 4.2 (n=26) G2: 5.2 ± 4.9 (n=27) Hyperactivity: G1: 18.5 ± 10.6 (n=26) G2: 18.6 ± 11.4 (n=27) Inappropriate speech: G1: 2.6 ± 2.8 (n=26) G2: 3.5 ± 3.6 (n=27) Adaptive behavior: Vineland daily living score, week 4, mean ± SD: G1: 43.6 ± 18.4 G2: 41.7 ± 17.0 (n=26)
| | | Hyperactivity: G1: 21.3 ± 10.3 (n=27) G2: 18.6 ± 9.6 (n=27) Inappropriate speech: G1: 2.6 ± 2.8 (n=27) G2: 2.9 ± 2.3 (n=27) Adaptive behavior: Vineland daily living G1: 43.3 ± 19.5 G2: 40.8 ± 16.9 (n=27) Vineland adaptive behavior composite G1: 38.2 ± 17.8 G2: 40.3 ± 18.4 Motor skills: DTVP-2 visual motor integration G1: 78.8 ± 20.9 (n=7) G2: 76.8 ± 23.5 (n=8) | Vineland adaptive behavior composite score, week 4, mean ± SD: G1: 39.1 ± 17.9 G2: 40.6 ± 18.1 Motor skills: DTVP-2 visual motor integration score, week 4, mean ± SD: G1: 79.6 ± 16.85 (n=6) G2: 74.4 ± 19.5 (n=8) Harms, n: Abdominal rash: 1 Non-febrile seizures: 1 Vomiting: 1 Flu-like symptoms: 1 Hyperactivity/problem behavior: 2 No harms clearly attributed to intervention Modifiers: NR

Roberts et al., 2001

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Roberts et al., 2001 Country: Canada Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: Randomized placebo controlled trial | Intervention: Porcine secretin or placebo, 2 occasions six weeks apart, 0.1 ml of secretin or saline placebo test dose. After vital signs were taken, 2 ml/kg (0.2 ml/kg) of secretin or saline was injected. Monitored for 4 hours Assessments: ADOS-G (baseline & both follow-ups), LIPS-R (baseline & final follow-up), PLS-II (baseline & both follow-ups), GSQ (baseline), Treatment Behavior/Side-Effect Rating Scale & Autism Behavior Checklist (end of each week) Groups: G1: porcine secretin G2: saline placebo Co-interventions held stable during treatment: NR Frequency of contact during study: 1 every 6 weeks Concomitant therapies, n (%): (If begun > 6 weeks before the baseline assessment) Selective serotonin reuptake inhibitors: G1: 1 (3) G2: 1 (3) Anticonvulsant: G1: 1 (3) G2: 1 (3) Stimulants: G1: 1^*^ (3) G2: 1^**^ (3) Melatonin: G1: 0 (0) G2: 1 (3) Ranitidine: G1: 0 (0) G2: 1 (3) | Inclusion criteria:; - Met criteria for Autism by ADI-R, ADOS-G, DSM-IV; Exclusion criteria:; - See inclusion criteria; Age, months ± SD: G1: 62.31 ± 14.86 G2: 63.16 ± 15.87 Mental age: Leiter IQ, mean ± SD: G1: 83.05 ± 22.48 G2: 77.85 ± 24.11 Gender, n (%): Male: G1: 26 (81) G2: 29 (91) Female: G1: 6 (19) G2: 3 (9) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In Study Diagnostic tool/method: ADI-R, ADOS-G, DSM-IV Diagnostic category, n (%): Autism: 64 (100) Other characteristics, n (%): GI symptoms: G1: 7 (22) G2: 8 (25) | Communication/language: PLS-3 score, mean ± SD: Expressive: G1: 17.03 ± 8.3 G2: 15.86 ± 10.28 Receptive: G1: 20.34 ± 10.01 G2: 19.48 ± 12.64 Total: G1: 53.9 ± 7.32 G2: 54.38 ± 10.88 Adaptive behavior: Autism Behavior Checklist subscale score, mean ± SD: Sensory: G1: 16.67 ± 6.69 G2: 15.14 ± 6.01 Relating: G1: 25.33 ± 9.31 G2: 23.64 ± 6.93 Body/object use: G1: 21.41 ± 10.78 G2: 18.21 ± 8.13 Language: G1: 18.15 ± 7.28 G2: 15.46 ± 7.48 Social/self-help: G1: 19.41 ± 4.39 G2: 17.75 ± 2.84 | Communication/language: PLS-3 score, mean ± SD: Expressive: G1: NR G2: NR ANOVA: time (performance increased; P < 0.05) treatment (P = NS) Receptive: G1: NR G2: NR ANOVA: time (performance increased; P < 0.05) treatment (P = NS) Total: G1: NR G2: NR ANOVA: time & treatment (P = NS) Adaptive behavior: Autism Behavior Checklist relating subscale, mean: G1: 27.91 ± NR G2: 21.08 ± NR G1/G2: P < 0.005 Harms, n (%): Rash: G1: 1 (3) G2: 0 Fever/tachycardia/vomiting: G1: 1 (3) G2: 0 Photosensitivity: G1: 1 (3) G2: 0 Irritability: G1: 3 (9) G2: 0 Generalized flushing of neck, face, chest: G1: 7 (22) G2: 0 Hyperactivity G1: 3 (9) G2: 3 (9)
| N at enrollment: G1: 34 G2: 34 N at follow-up: G1: 32 G2: 32 | | | Aggression G1: 2 (6) G2: 1 (3) Modifiers: No significant treatment differences noticed when analysis was done by subgroups (GI symptoms, IQ, or history of regression)

Comments:

* dextroamphetamine

** methylphenidate

Stahmer et al., 2001

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Stahmer et al., 2001 Country: US Practice setting: Tertiary care hospital, academic Intervention setting: Clinic Enrollment period: NR Funding: United Way Author industry relationship disclosures: NR Design: Prospective cohort | Intervention: Parent information support group, 1 hr/week for 12 weeks (G1 only) Parent education course on pivotal response training (PRT), also 1 hr/week for 12 weeks (both groups) Assessments: BSID, MDI, MCDI, 5-minute videotapes of parents interacting with children before and after treatment to assess parent use of program techniques and child’s words Groups^**^: G1: Parent support group and education course G2: Parent education course only Ga: Parents met criteria for mastery of PRT post-treatment (correct use of PVT techniques in > 75% of intervals scored) Gb: Parents did not meet criteria for mastery of PRT Provider:; - For parent education content: first author served as parent educator (clinical director of a hospital-based autism intervention center and research scientist); - For information support group: second author served as group facilitator (director of a children’s hospital department of developmental services, not formally trained in PRT); Measure of treatment fidelity reported: NR | Inclusion criteria:; - Age < 5 years; - Recent ASD diagnosis; - Initial diagnosis within the 6-month period preceding participation in the education program; Exclusion criteria:; - See inclusion criteria; Age, months (range): G1: 35 (19–48) G2: 35.6 (29–50) Mental age: BSID II developmental age, months (range): G1: 51 (<50–90) G2: 51 (<50–85) Gender: NR Race/ethnicity: NR SES: Maternal education: NR Household income, n: > $50,000: G1: 9 G2: 6 $40,000–$50,000: G1: 0 G2: 4 $30,000–$40,000: G1: 0 G2: 0 $20,000–$30,000: G1: 1 G2: 0 $10,000–$20,000: G1: 1 G2: 1 Diagnostic approach: Referral Diagnostic tool/method: NR Diagnostic category, n (%): ASD: 22 (100) | Communication/language: MCDI, words understood, mean: Ga: 119 Gb: 160 Ga/Gb: P = NS MCDI, words produced, mean: Ga: 29 Gb: 57 Ga/Gb: P = NS MCDI, communicative gestures, mean: Ga: NR Gb: NR Words used during videotaped play, mean: Ga: NR Gb: NR | Communication/language: Correct use of PRT techniques, % of intervals scored, mean (range): G1: 75 (68–86) G2: 60 (29–78) G1/G2: P < 0.05 Parents met criteria for mastery (correct use of PRT techniques in > 75% of intervals scored), n: G1: 8 G2: 4 MCDI, words understood, mean change: Ga: 135 Gb: 28 Ga/Gb: P < 0.01 MCDI, words produced, mean change: Ga: 69 Gb: 32 Ga/Gb: P < 0.01 MCDI, communicative gestures, mean change: Ga: NR^*^ Gb: NR^*^ Ga/Gb: P = NS Words used during videotaped play, mean change: Ga: NR Gb: NR Ga/BL: P < 0.05 Gb/BL: P < 0.05 Ga/Gb: P = NS Harms: NR Modifiers: NR
| Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 11 G2: 11 N at follow-up: G1: 11 G1a: 8 G1b: 3 G2: 11 G2a: 4 G2b: 7 | Other characteristics: Marital status, n: Married: G1: 10 G2: 10 Widow: G1: 1 G2: 0 Single: G1: 0 G2: 1

Comments:

* Data only illustrated graphically.

** Enrollment in G1 vs. G2 was non-randomized and depended on availability on enrollment in patient education program; if group was available, it was a requirement for participation.

Tjus et al., 2001

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Tjus et al., 2001 Country: Sweden Practice setting: Academic Intervention setting: School Enrollment period: NR Funding: Swedish Council of Social Research, Queen Silvia’s Jubilee Fund for Research on Children and Handicaps Author industry relationship disclosures: NR Design: Prospective case series | Intervention: Swedish version of the Alpha program (a multimedia program for increasing literacy skills and language learning through voice, animation, video, and sign language feedback); 25.6 ± 7.5 sessions lasting 32.0 ± 12.6 minutes over 16.9 ± 5.7 weeks Assessments: Videotaped sessions of children and their teachers evaluated at start and end of training to assess 15 variables of verbal and non-verbal behavior; observations coded by one of the authors. All interviews and observations conducted by a psychologist who was not blind to group assignment. Groups: G1: autism Provider: Four teachers Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 11 N at follow-up: G1: 11 | Inclusion criteria:; - Confirmed diagnosis of autism according to DSM-III-R; Exclusion criteria:; - See inclusion criteria; Age, months ± SD: G1: 112 ± 28 Mental age (CPM), months ± SD: G1: 81 ± 25 Gender, n: Male: 9 Female: 2 Race/ethnicity: NR SES: NR Diagnostic approach: Referral Diagnostic tool/method: DSM-III-R Diagnostic category, n (%): Autism: 11 (100) Other characteristics: RDLS language age, months ± SD: 57 ± 22 CARS score, median (range): 42 (21.5–57) | Social skills: Enjoyment, median frequency (range): G1: 4 (0–15) Communication/language: Verbal expressions, median frequency (range): G1: 29 (4–44) Problem behavior: Ignores, median frequency (range): G1: 1 (0–10) Off task, median frequency (range): G1: 2 (0–26) Protests, median frequency (range): G1: 0 (0–10) Adaptive behavior: Complies, median frequency (range): G1: 9 (4–21) Seeks help, median frequency (range): G1: 0 (0–4) | Social skills: Enjoyment, median frequency (range): G1: 10 (0–20), G1/BL: P < 0.05 Communication/language: Verbal expressions, median frequency (range): G1: 37 (4–49) G1/BL: P < 0.02 Problem behavior: Ignores, median frequency (range): G1: 1 (0–7) G1/BL: P = NS Off task, median frequency (range): G1: 6 (2–18) G1/BL: P = NS Protests, median frequency (range): G1: 0 (0–2) G1/BL: P = NS Adaptive behavior: Complies, median frequency (range): G1: 7 (3–20) G1/BL: P = NS Seeks help, median frequency (range): G1: 2 (0–9) G1/BL: P < 0.05 Harms: NR Modifiers: Teacher recasts correlated with pre- and post-treatment verbal expressions (P < 0.05)

## 2000

Chez et al. 2000

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Chez et al. 2000 Country: US Practice setting: Clinic Intervention setting: Clinic Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: Study 1: Prospective case series Study 2: Not included (N < 30) | Intervention: Study 1: Secretin, 2 IU/kg per kg of body weight over 1–2 mins Assessments: CARS at baseline and post injection office visits Physicians or nurses assessed GI function, eye contact, expressive speech, and receptive language; parents noted changes in eye contact, interpersonal relations, self-stimulatory behavior, bowel movement consistency, toy play, expressive language/verbalizations, receptive language, and overall behavior with observational diaries; observed for 1 hour post-injection Groups: G1: secretin Co-interventions held stable during treatment: NR Frequency of contact during study: Study 1: 2 times, follow-up (3.7 ± 1.4 weeks; range 3–6 weeks) Concomitant therapies, n (%): Other drug treatments: 45 (80.4) Antidepressants: 9 (16.1) CNS stimulants: 9 (16.1) N at enrollment: G1: 56 N at follow-up: G1: 56 | Inclusion criteria:; - Met DSM-IV criteria for PDDNOS or Autistic disorder; Exclusion criteria:; - See inclusion criteria; Age, years ± SD: 6.4 ± 2.7 Mental age: NR Gender, n (%): Male: 49 (88) Female: 7(13) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: Self-Referral Diagnostic tool/method: DSM-IV Diagnostic category, n (%): Autism: 22 (40) PDD-NOS: 34 (60) Other characteristics, n (%): GI distress: 33 (59) Abnormal EEG: 31 (63) | Overall ratings: CARS score, mean ± SD: G1: 36.5 ± 6.4 | Overall ratings: CARS score, mean ± SD: G1: 33.2 ± 5.4 G1/BL: P < 0.01 CARS score, decrease from baseline, n: ≥ 6 (clinically meaningful): 13 1 to 5.5: 32 0 (no change): 2 −0.5 to −11 (worsening): 9 Social skills, n (%): Improved eye contact: 19 (34) Communication/language, n (%): Improved expressive language: 30 (34) Receptive speech improvements: 15 (27) Improvements in expressive speech: 30 (54) Improvements in receptive speech: 15 (27) Worsening of expressive speech: 1 (1.8) Medical, n (%): Improved GI: 19 (34) Worsening of GI function & eye contact: 1 (1.8) Harms: Reports of increased agitation, decreased focusing & decreased responsiveness to others Modifiers: NR

Dunn-Geier et al., 2000

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Dunn-Geier et al., 2000 Country: Canada Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: Children’s Hospital Eastern Ontario Research Institute; PA Woodward’s Foundation; Children at Risk Ottawa Author industry relationship disclosures: NR Design: RCT, double blind, placebo controlled; stratified by site and age | Intervention: Single dose of secretin (test dose 0.1 CU injected through saline lock; if no immediate hyper-sensitivity occurred after 1 minute, injection of 2 CU/kg (0.2 ml/kg) to a maximum of 1 vial (75 CU)) Assessments: Autism Behavior Checklist, GI symptoms and side effect questionnaire designed for study completed by parents; CARS administered by observer in clinic Groups: G1: secretin G2: placebo (saline) Co-interventions held stable during treatment: Yes Frequency of contact during study: At baseline; injection (up to 1.5 hours post-injection); and 3 week follow-up Concomitant therapies, n (%): ABA: G1: 15 (33) G2: 24 (51) Speech: G1: 37 (79) G2: 34 (72) Floor time: G1: 5 (12) G2: 4 (10) Magnesium B6: G1: 1 (2) G2: 4 (9) DMG3: G1: 2 (5) G2: 3 (6) School/preschool placement: G1: 41 (91) G2: 42 (91) | Inclusion criteria:; - Diagnosis of autism based on behavioral observation of the child and semistructured interview with the parent (CARS score ≥ 30); - Score of ≥ 6 on DSM-IV criteria for autism; - Clinical judgment by a development pediatrician and a registered psychologist experienced in the field of PDD; Exclusion criteria:; - Patients with recognizable neurological or genetic disorder; - Pancreatic or liver disorder; - Allergy to lidocaine or prilocaine; - Previous use of secretin; - Any treatment initiated or changed within the 2 months immediately before enrollment; - Any treatment planned to begin within the 3 weeks after injection; Age, years ± SD: G1: 5.1 ± 1.2 G2: 5.1 ± 1.4 Mental age: NR Gender, n (%): Male: G1: 42 (89) G2: 46 (96) Female: G1: 5 (11) G2: 2 (4) Race/ethnicity, n (%): White: G1: 34 (72) G2: 41 (85) SES: NR Diagnostic approach: In study | Overall ratings: CARS score, mean ± SD: G1: 38.5 ± 4.5 G2: 37.9 ± 4.4 Autism Behavior Checklist, total score, mean ± SD: G1: 79.0 ± 31.6 G2: 79.9 ± 26.9 Autism Behavior Checklist body and object use score, mean ± SD: G1: 17.5 ± 9.4 G2: 17.0 ± 8.7 Social skills: Autism Behavior Checklist socialization score, mean ± SD: G1: 14.7 ± 5.9 G2: 15.3 ± 5.4 Autism Behavior Checklist social related-ness score, mean ± SD: G1: 19.1 ± 8.3 G2: 19.1 ± 8.6 Communication/language: PLS total score, mean ± SD G1: 25.2 ± 11.8 G2: 31.0 ± 15.6 PLS auditory comprehension score, mean ± SD: G1: 12.2 ± 7.5 G2: 16.2 ± 19.2 PLS expressive communication score, mean ± SD: G1: 12.9 ± 4.8 G2: 14.6 ± 7.0 ABC language score, mean ± SD: G1: 13.3 ± 7.6 G2: 13.5 ± 6.7 | Overall ratings: CARS score, mean change (SE): G1: −1.2 (0.3) G2: −1.5 (0.4) G1/G2: P = 0.62 Autism Behavior Checklist, total score, mean change (SE): G1: −13.1 (2.6) G2: −14.0 (2.7) G1/G2: P = 0.81 Autism Behvaior Checklist body and object use score, mean change (SE): G1: −2.6 (0.9) G2: −2.7 (0.9) G1/G2: P = 0.89 Social skills: Autism Behavior Checklist socialization score, mean change (SE): G1: −2.5 (0.6) G2: −2.1 (0.8) G1/G2: P = 0.64 Autism Behavior Checklist social relatedness score, mean change (SE): G1: −3.9 (1.0) G2: −4.0 (1.0) G1/G2: P = 0.90 Communication/language: PLS total score, mean change (SE): G1: 2.4 (0.8) G2: 1.1 (0.6) G1/G2: P = 0.25 PLS auditory comprehension score, mean change (SE): G1: 1.5 (0.6) G2: 0.6 (0.4) G1/G2: P = 0.2
| Medication: G1: 9 (19) G2: 5 (11) N at enrollment: G1: 47 G2: 48 N at follow-up: G1: 47 G2: 48 | Diagnostic tool/method: CARS, DSM-IV Diagnostic category, n (%): Autism: 95 (100) PDD-NOS: 0 Aspergers: 0 Other characteristics: Height, cm ± SD: G1: 108.6 ± 8.4 G2: 111.2 ± 9.9 Weight, kg ± SD: G1: 19.8 ± 3.5 G2: 21.3 ± 6.1 Seizure, n (%): G1: 3 (6) G2: 2 (4) Abnormal CT, n (%): G1: 1 (2) G2: 1 (2) Cognitive measure, mean ± SD: G1: 38.1 ± 19.4 G2: 39.8 ± 16.2 | Medical: Number of GI problems, mean ± SD: G1: 1.0 ± 1.1 G2: 1.2 ± 1.2 Sensory: Autism Behavior Checklist sensory score, mean ± SD: G1: 13.3 ± 7.4 G2: 13.9 ± 6.5 | PLS expressive communication score, mean change (SE): G1: 0.6 (0.4) G2: 0.6 (0.4) G1/G2: P = 0.93 Improvement on PLS-3 scale ≥ 4 (small), n (%): G1: 16 (34) G2: 10 (21) G1/G2: P = 0.17 Improvement on PLS-3 scale ≥ 6 (moderate/large), n (%) G1: 8 (17) G2: 4 (8) G1/G2: P = 0.23 Autism Behavior Checklist language score, mean change (SE): G1: −0.9 (0.6) G2: −1.8 (1.0) G1/G2: P = 0.46 Medical: Number of GI problems, mean change (SE): G1: −0.4 (0.2) G2: −0.2 (0.1) G1/G2: P = 0.35 Sensory: Autism Behavior Checklist sensory score, mean change (SE): G1: −2.4 (0.8) G2: −2.7 (0.9) G1/G2: P = 0.77 Harms: Tachycardia: 0 Edema/swelling: 0 Headache: 0 Dizziness/light-headedness: 0 Nausea/vomiting: 0 Skin rash/pruritis: 0 Abdominal pain: 0 Flushing G1: 3 G2: 4
| | | | Modifiers: Mean difference between groups for PLS-3 total score is still not significant when analysis is limited to patients with at least one GI problem.

Harris et al., 2000

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Harris et al., 2000 Country: US Practice setting: Academic Intervention setting: Classroom Enrollment period: 1990 to 1992 Funding: NR Author industry relationship disclosures: NR Design: Prospective Case Series | Intervention: Intensive applied behavioral analysis treatment program, 35–45 hours weekly, 5 days a week for 12-months. Each family was expected to provide an additional 10 to 15 hours a week of home-based instruction. Questionnaire sent to parents about current educational placement. Assessments: IQ & CARS included in follow-up questionnaire 7 years after entry into preschool classroom of the DDDC Groups: G1: intensive applied behavior analysis Provider: Therapists at Douglass Developmental Disabilities Center (DDDC) Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 27 N at follow-up: G1: 27 | Inclusion criteria:; - Met DSM-III-R criteria for autism by outside source and confirmed by clinical psychologist at intake; - Entered Douglass Developmental Disabilities Center between 1990–1992; - Every child with data on pre, post IQ data, CARS at baseline and age at admission; Exclusion criteria:; - See Inclusion criteria; Age at admission, mean/mos (range): 49 (31–65) Age at follow-up, mean/mos (range): 142 (122–170) Mental age: NR Gender, n (%): M: 23 (85) F: 4 (15) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: In study Diagnostic tool/method: DSM III-R clinical interview Diagnostic category, n (%): Autism 27(100) Other characteristics: NR | Overall measures: CARS, mean (range): G1: 34.17 (range 30–40) Educational/cognitive/academic attainment: Stanford Binet (IQ), mean (range): G1: 59 (range 35–109) | Educational/cognitive/academic attainment: IQ, mean: 77.59 Harms: NR Modifiers: Significant association between age at admission and academic placement r(25) = 0.658, P < 0.005 (younger students more likely to be in regular education settings at follow-up) Treatment before 48mo: 10/13 in regular education settings Treatment after 50months: 1/14 in a regular class (Fisher exact test P <0.005) Significant association between higher IQ at admission and the greater likelihood of a regular education, mean: 77.59 r(25) = 0.655, P < 0.005 IQ ≤ 52 at intake in regular setting: 1/14 IQ ≤ 52 at intake in special education: 13/14
| | | | IQ ≥ 59 at intake in regular education: 10/13 IQ ≥ 59 at intake in special education: 3/13 Discharge IQ ≥ 80 in regular classes: 11/13 Discharge IQ ≥ 80 in special education: 3/13 IQ ≤ 76 at discharge in special education: 13/13 (P < 0.005) Significant association between age at intake and IQ when child left program (P < 0.025); younger children at intake had higher IQs at discharge No significant correlations between age and IQ at intake, or between CARS score at intake and education setting at follow-up.

Luiselli et al., 2000

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Luiselli et al., 2000 Country: US Practice setting: Specialty treatment center Intervention setting: Home Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: retrospective case series; children randomly selected (unspecified methodology) from those of specific age groups for analysis | Intervention: home-based treatment based on Lovaas and described by Anderson (1987) Groups: G1a: initiated treatment at under 3 years of age G1b: initiated treatment at over 3 years of age Duration, mean months ± SD: G1a: 11.6 ± 7.00 G1b: 7.12 ± 2.41 Frequency, mean hours/week ± SD: G1a: 11.8±3.72 G1b: 15.6±1.76 Total hours (mean±SD): G1a: 583.50 ± 435.27 G1b: 455.00 ± 204.17 Assessments: Pretreatment: standardized instruments (service delivery & ELAP or LAP), direct observations, parent interviews, and videotape segments; completed by May Center for Early Childhood Education staff Provider: Therapists with BA or MA degrees with specializations in psychology, early childhood education, or special education, training in procedures, and weekly supervision and case consultation from director of home-based services Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR | Inclusion criteria:; - In receipt of home-based services from May Center for Early Childhood Education; - Diagnosed as having autism or pervasive developmental disorder by evaluators not associated with the center (method not provided); Exclusion criteria:; - See inclusion criteria; Age, mean/yrs (range): G1a: 2.63 years G1b: 3.98 years Mental age: NR Gender: NR Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: See inclusion criteria Diagnostic tool/method: NR Diagnostic category, n (%): G1a: Global developmental delay: 1 (12.5) PDD: 2 (25) PDD-NOS: 3 (37.5) Autistic disorder: 1 (12.5) PDD/autistic disorder: 1 (12.5) G1b: Developmental delay: 1 (12.5) PDD: 6 (75) Autistic disorder: 1 (12.5) Other characteristics: NR | Early Learning Accomplishments Profile (ELAP) or Learning Accomplishments Profile (LAP); baseline values not provided. Only change data presented. | Communication/language: ELAP/LAP Communication, mean change ± SD: G1a: 21.00 ± 18.42 (P = 0.015) G1b: 8.25 ± 10.11 (P = 0.054) Educational/cognitive/academic attainment: Cognitive, mean change ± SD: G1a: 21.00 ± 15.38 (P = 0.006) G1b: 11.25 ± 6.75 (P = 0.002) Motor skills: Fine motor, mean change ± SD: G1a: 20.75 ± 21.88 (P = 0.031) G1b: 13.50 ± 12.31 (P = 0.017) Gross motor, mean change ± SD: G1a: 16.85 ± 16.15 (P = 0.036) G1b: 10.50 ± 11.89 (P = 0.041) Adaptive behavior: Self-Care, mean change ± SD: G1a: 15.00± 12.82 (P = 0.013) G1b: 12.75 ± 11.31 (P = 0.015) Social skills: Social-Emotional, mean change ± SD: G1a: 24.00 ± 21.98 (P = 0.018) G1b: 17.25 ± 12.18 (P = 0.005)
| Concomitant therapies: NR N at enrollment: G1a: 8 G1b: 8 N at follow-up: G1a: 8 G1b: 8 | | | Harms: NR Modifiers: Duration of treatment predicted change scores and was significant for communication (P < 0.002), cognition (P < 0.001) and social-emotional (P < 0.001) domains.

Moore et al., 2000

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Moore et al., 2000 Country: US Practice setting: Academic Intervention setting: School Enrollment period: NR Funding: NR Author industry relationship disclosures: NR Design: RCT | Intervention: Children taught 6 nouns (3/day for two days) by teacher or computer instruction with follow-up testing at 1 week post-intervention Assessment: Learning, attention & motivation measures Groups: G1: Teacher (Behavioral) G2: Computer software program (Educational) Provider:; - Teacher; - Computer; Measure of treatment fidelity reported: No Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 7 G2: 7 N at follow-up: G1: 7 G2: 7 | Inclusion criteria:; - Children with autism enrolled at one school; Exclusion criteria:; - See inclusion criteria; Age, range: 3–6 years Mental age: NR Gender, n (%): M: 12 (85.7) F: 2 (14.3) Race/ethnicity: NR SES: Maternal education: NR Household income: NR Diagnostic approach: NR Diagnostic tool/method: NR Diagnostic category, n (%): Autism: 14 (100) Other characteristics: 5 of 7 children in G2 had used a computer and knew how to use a mouse; the other two were given an initial practice session All children in G1 had previously experienced behavioral training | NR | Social skills: Amount of time spent paying attention to instruction, %: G1: 62 G2: 97 F(1,13) = 13.28, P < 0.01 Communication/language: Nouns recalled, mean (%): G1: 2.43 (41) G2: 4.43 (74) F(1,13) = 10.89, P < 0.01 Educational/cognitive/academic attainment: Interest in continuing intervention at end of session vs. going to play, %: G1: 0 G2: 56 P < 0.05 Harms: NR Modifiers: The more children attended in either condition, the more they learned F(1,13) = 38.45 (P < 0.001)

Mudford et al., 2000

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Mudford et al., 2000 Country: UK Practice setting: Academic Intervention setting: Clinic Enrollment period: NR Funding: National Health Service Research and Development Programme for People with Physical and Complex Disabilities Author industry relationship disclosures: NR Design: RCT, crossover design | Intervention: Auditory integration training using Audio Tone Enhancer/Trainer CD player and headphones 10 hours training across 10 consecutive working days, 2 30-minute sessions per day at least 3.5 hours apart Children were observed for average 3.83 hours across one school day monthly, except month 12 Study was 14 months total, with 3–5 months of pretreatment baseline and at least 4 months between treatments Groups: G1: auditory integration therapy--control G2: control–auditory integration therapy Provider: Persons trained by a Director of the Society of Auditory Intervention Techniques; trainer and assistants had at least 4 years experience working with children with autism and problem behaviors Assessments: Vineland Adaptive Behavior Composite Reynell Developmental Language Scales-III Leiter International Performance Scale Aberrant Behavior Checklist Nisonger Child Behavior Rating Form Measure of treatment fidelity reported: No | Inclusion criteria:; - Diagnosis of autism confirmed by DSM-IV and ICD-10 by consultant psychologists; Exclusion criteria:; - See inclusion criteria; Age, mean/yrs ± SD (range): 9.42 years ± 29 months (5.75–13.92 years) Mental age: NR Gender, n (%): M: 17 (81) F: 4 (19) Race/ethnicity, n (%): NR SES: Maternal education: NR Household income: NR Diagnostic approach: In study Diagnostic tool/method: Confirmed based on ICD-10 and SDM-IV classifications by previous assessments, direct observation and discussion with teachers Diagnostic category, n (%): Autism: 16 (100) Other characteristics: IQ for 15 for whom it was available, mean (range): 56 (8–125) | Problem behavior: ABC-P hyperactivity, mean ± SD 23.7 ± 9.4 NCBRF-P hyperactive, mean ± SD: 13.9 ± 5.5 Educational/cognitive/academic attainment: Leiter IQ (n=11), mean: 68 Adaptive behavior: VABS composite, mean: 31 Communication/language: Derived language quotient (age equivalent/chronological age × 100), mean: 26 Language comprehension quotient, mean: 28 Comprehension age/months equivalent, mean: 31 Reynell Language Development Scales-III expressive language age equivalents: 28 Medical: Ear occlusion, % mean ± S D: 8.2 ± 12.8 | Change at Audio Integration Training Problem behavior: ABC-P hyperactivity, mean ± SD: 0.3 ± 3.6 (P < 0.05) NCBRF-P hyperactive, mean ± SD: −0.3 ± 2.0 (P < 0.10) Change at control Problem behavior: ABC-P hyperactivity, mean ± SD: −4.1 ± 3.9 NCBRF-P hyperactive, mean ± SD: −2.0 ± 2.2 Educational/cognitive/academic attainment: Leiter IQ (n=11), mean: 66 (P = NS) Adaptive behavior: VABS composite, mean: 29 t(15) = 3.36 P = 0.004 Communication/language: Derived language quotient (age equivalent/chronological age × 100), mean: 24, t(15) = 2.01, (P = 0.06)
| Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: 21 N at follow-up: 16 G1: 7 G2: 9 | | | Language comprehension quotient, mean: 26 (P = NS) Reynell Language Development Scales-III comprehension age equivalents described as unchanged across the study, mean/months: 31 Reynell Language Development Scales-III expressive language age equivalents: 29, t(15) = 1.83, P = 0.09 Medical: Ear occlusion, change at audio integration training, % mean ± SD: 3.7% ± 5.9 P < 0.10 Ear occlusion, Change at control, % mean ± SD: 1.2 ± 6.4 Harms, n: Diarrhea: 1 Excessive sleepiness: 1 More distraught: 1 Modifiers: NR

Smith et al. 2000

Study Description | Intervention | Inclusion/Exclusion Criteria/Population | Baseline Measures | Outcomes
Author: Smith et al. 2000 Country: US Practice setting: Specialty treatment center Intervention setting: Clinic, Home Enrollment period: 1989 to 1992 Funding: Department of education & UCLA Regents Author industry relationship disclosures: NR Design: RCT | Intervention: Intensive training, 30 hrs/week for 2–3 years from therapist, parent with therapist 5 hrs/week for first 3 months Parent intervention, families taught techniques from Lovaas manual 2 sessions/week in homes for 3–9 months Assessments: Once intake assessments had been completed on 4–8 children, they were divided into 2 cohorts (autism & PDD); children were paired by statistician on IQ (Bayley), and then randomly assigned 1 member of each pair to treatment or parent-training group Groups: G1: intensive training G2: parental training Provider: Therapists in UCLA Young Autism Project Measure of treatment fidelity reported: Yes Co-interventions held stable during treatment: NR Concomitant therapies: NR N at enrollment: G1: 15 G2: 13 N at follow-up: G1: 15 G2: 13 | Inclusion criteria:; - 18–42 months at time of referral; - Residence within 1 hr of UCLA center; - IQ between 35–75; - Diagnosis of ASD or PDD-NOS; - Absence of major medical problems; Exclusion criteria:; - See inclusion criteria; Age, mean/months ± SD: At Intake: G1: 36.07 ± 6.00 G2: 35.77 ± 5.37 Follow-up: G1: 94.07 ± 13.17 G2: 92.23 ± 17.24 Mental age: NR Gender, n (%): M: G1: 12 (80) G2: 11 (85) F: G1: 3 (20) G2: 2 (15) Race/ethnicity, n (%): White: G1: 7 (47) G2: 7 (54) Hispanic: G1: 4 (26) G2: 2 (15) Black: G1: 1 (7) G2: 3 (23) Asian: G1: 3 (20) G2: 1 (8) SES: Maternal education, median (range): G1: 12 (10–16+) G2: 15 (12–16+) Paternal education, median (range): G1: 13–14 (<6–16+) G2: 15 (12–16+) | Educational/cognitive/academic attainment: Stanford Binet or Bayley Scales of Infant Development-Mental Development Index (scored as IQ), mean ± SD: G1: 50.53 ± 11.18 G2: 50.69 ± 13.88 Merrill-Palmer Scale of Mental Tests, mean ± SD: G1: 21.60 ± 4.49 G2: 21.92 ± 5.50 Communication/language: Reynell Development Language Scale Total, mean ± SD: G1: 28.60 ± 4.07 G2: 30.00 ± 6.34 Comprehension, mean ± SD: G1: 13.47 ± 3.60 G2: 13.69 ± 3.73 Expressive, mean ± SD: G1: 15.13 ± 0.52 G2: 16:31 ± 2.69 Developmental Language Scale G1:69.93(8.37) G2:70.62(11.50) Adaptive Functioning Vineland Adaptive Behavior Scales Composite, mean ± SD: G1: 63.4 ± 9.35 G2: 65.2 ± 9.44 Communication, mean ± SD: G1: 58.20 ± 5.56 G2: 62.00 ± 6.11 | Educational/cognitive/academic attainment: Bayley Scales of Infant Development-Mental Development Index (scored as IQ), mean ± SD: G1: 66.49 ± 24.08 G2: 49.67 ± 19.74 P < 0.05 Merrill-Palmer Scale of Mental Tests, mean ± SD: G1: 64.33 ± 18.74 G2: 49.17 ± 21.43 P < 0.05 Communication/language: Reynell Development Language Scale Total, mean ± SD: G1: 87.40 ± 46.21 G2: 61.33 ± 31.88 P < .05 Comprehension, mean ± SD: G1: 42.87 ± 22.29 G2: 33.00 ± 16.86 P = NS Expressive, mean ± SD: G1: 44.53 ± 23.48 G2: 36.23 ± 21.19 P = NS Developmental Language Scale, mean ± SD: G1: 62.33 ± 25.76 G2: 63.00 ± 16.97 P = NS
| | Household income, median (range): G1: 40–50,000 (<10,000 to 75–100,000) G2: 40–50,000 (<10,000 to 75–100,000) Diagnostic approach: Referral-Independent diagnosis from psychologist at State regional developmental coordination center. 19 received second independent diagnosis Diagnostic tool/method: NR Diagnostic category, n (%): Autism: 14 (50) PDD-NOS: 14 (50) Other characteristics: Motor delays: G1: 2 G2: 1 | Socialization, mean ± SD: G1: 62.4 ± 7.82 G2: 69.15 ± 8.75 Daily Living, mean ± SD: G1: 69.93 ± 8.37 G2: 70.62 ± 11.50 | Adaptive Functioning Vineland Adaptive Behavior Scales Composite, mean ± SD: G1: 61.19 ± 29.72 G2: 58.50 ± 16.58 P = NS Communication, mean ± SD: G1: 67.87 ± 30.08 G2: 60.77 ± 17.26 P = NS Socialization, mean ± SD: G1: 66.33 ± 24.78 G2: 68.92 ± 16.94 Daily Living, mean ± SD: G1: 62.33 ± 25.76 G2: 63.00 ± 16.97 Academic Achievement Wechsler Individualized Achievement Test, mean ± SD: G1: 75.51 ± 21.31 G2: 58.44 ± 18.43 Harms NR Modifiers NR