# Sample Data Abstraction Forms

Abstract Review Form

Full Text Review Form

Relevance Review Form for Previous Systematic Reviews (2008-09)

Quality Review Form for Previous Systematic Reviews (2008-09)