# Exact Search Strings and Results

Table A1 PubMed search strategies (all searches last updated May 10, 2010)

Search terms | | Search results
#1 | Autistic[tiab] OR autism[tiab] OR autistic disorder[mh] OR asperger syndrome[mh] OR child development disorders, pervasive[mh:noexp] OR asperger[tiab] OR asperger’s[tiab] OR aspergers[tiab] OR pervasive development[tiab] OR pervasive developmental[tiab] OR pdd[tiab] | 17,936
#2 | therapy[sh] OR therapeutics[mh] OR teaching[mh] OR psychotherapy[mh] OR treatment outcome[mh] | 5,713,136
#3 | #1 AND #2 AND eng[la] AND humans[mh] | 4,712
#4 | #3 AND newspaper article[pt] | 1
#5 | #3 AND letter[pt] | 264
#6 | #3 AND comment[pt] | 158
#7 | #3 AND case reports[pt] | 811
#8 | #3 AND review[pt] | 854
#9 | #3 AND practice guideline[pt] | 6
#10 | #3 AND news[pt] | 48
#11 | #3 AND editorial[pt] | 73
#12 | #3 AND historical article[pt] | 27
#13 | #3 AND meta-analysis[pt] | 26
#14 | #3 AND legal cases[pt] | 6
#15 | #3 AND published erratum[pt] | 1
#16 | #3 AND congresses[pt] | 8
#17 | #3 NOT (#4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16) | 2,723^*^

Key: [mh] Medical Subject Heading; [mh] Medical Subject Heading, not exploded; [tiab] title/abstract word; [pt] publication type; [sh] subheading

* Note: numbers do not tally as some articles are excluded in more than one category; 12 articles were case reports, comments, and letters; 73 were case reports and letters; 51 were case reports and reviews; 12 were meta-analyses and reviews; 15 were comments and editorials; 1 was a comment, editorial, and review; 95 were comments and letters; 3 were comments and reviews; 2 were reviews and practice guidelines; 1 was an editorial and practice guideline; 8 were historical articles and reviews; 2 were case reports and historical articles; 2 were case reports and editorials; 1 was a case report and meta-analysis; 1 was a case report and a legal case; 3 were editorials and reviews; 1 congresses and case reports.

Table A2 PsycINFO search strategies (CSA interface)

Search terms | | Search results
#1 | DE=(“pervasive developmental disorders” or “aspergers syndrome” or “autism”) | 16,454
#2 | DE=(“treatment” or “adjunctive treatment” or “aftercare” or “alternative medicine” or “acupuncture” or “aromatherapy” or “faith healing” or “folk medicine” or “behavior modification” or “behavior therapy” or “aversion therapy” or “covert sensitization” or “conversion therapy” or “dialectical behavior therapy” or “exposure therapy” or “implosive therapy” or “systematic desensitization therapy” or “reciprocal inhibition therapy” or “response cost” or “biofeedback training” or “classroom behavior modification” or “contingency management” or “token economy programs” or “fading conditioning” or “omission training” or “overcorrection” or “self management” or “self instructional training” or “time out” or “bibliotherapy” or “cognitive techniques” or “cognitive restructuring” or “cognitive therapy” or “self instructional training” or “computer assisted therapy” or “creative arts therapy” or “art therapy” or “dance therapy” or “music therapy” or “poetry therapy” or “recreation therapy” or “crisis intervention services” or “hot line services” or “suicide prevention centers” or “cross cultural treatment” or “cross cultural counseling” or “disease management” or “health care services” or “continuum of care” or “long term care” or “mental health services” or “community mental health services” or “palliative care” or “primary health care” or “interdisciplinary treatment approach” or “involuntary treatment” or “medical treatment general” or “gene therapy” or “milieu therapy” or “movement therapy” or “multimodal treatment approach” or “online therapy” or “outpatient treatment” or “outpatient commitment” or “partial hospitalization” or “personal therapy” or “physical treatment methods” or “acupuncture” or “artificial respiration” or “deep brain stimulation” or “drug therapy” or “hormone therapy” or “narcoanalysis” or “sleep treatment” or “polypharmacy” or “vitamin therapy” or “electrosleep treatment” or “gene therapy” or “phototherapy” or “psychosurgery” or “thalamotomy” or “radiation therapy” or “shock therapy” or “electroconvulsive shock therapy” or “insulin shock therapy” or “surgery” or “brain stimulation” or “brain self stimulation” or “chemical brain stimulation” or “electrical brain stimulation” or “spreading depression” or “transcranial magnetic stimulation” or “preventive medicine” or “psychotherapeutic techniques” or “animal assisted therapy” or “autogenic training” or “cotherapy” or “dream analysis” or “guided imagery” or “mirroring” or “morita therapy” or “motivational interviewing” or “mutual storytelling technique” or “paradoxical techniques” or “psychodrama” or “psychotherapy” or “adlerian psychotherapy” or “adolescent psychotherapy” or “analytical psychotherapy” or “autogenic training” or “behavior therapy” or “aversion therapy” or “covert sensitization” or “conversion therapy” or “dialectical behavior therapy” or “exposure therapy” or “implosive therapy” or “systematic desensitization therapy” or “reciprocal inhibition therapy” or “response cost” or “brief psychotherapy” or “child psychotherapy” or “play therapy” or “client centered therapy” or “cognitive behavior therapy” or “acceptance and commitment therapy” or “eclectic psychotherapy” or “emotion focused therapy” or “existential therapy” or “experiential psychotherapy” or “expressive psychotherapy” or “eye movement desensitization therapy” or “feminist therapy” or “geriatric psychotherapy” or “gestalt therapy” or “group psychotherapy” or “encounter group therapy” or “marathon group therapy” or “therapeutic community” or “guided imagery” or “humanistic psychotherapy” or “hypnotherapy” or “age regression hypnotic” or “individual psychotherapy” or “insight therapy” or “integrative psychotherapy” or “interpersonal psychotherapy” or “logotherapy” or “narrative therapy” or “persuasion therapy” or “primal therapy” or “psychoanalysis” or “dream analysis” or “self analysis” or “psychodrama” or “psychodynamic psychotherapy” or “psychotherapeutic counseling” or “family therapy” or “conjoint therapy” or “rational emotive behavior therapy” or “reality therapy” or “relationship therapy” or “solution focused therapy” or “supportive psychotherapy” or “transactional analysis” or “rehabilitation” or “cognitive rehabilitation” or “criminal rehabilitation” or “drug rehabilitation” or “alcohol rehabilitation” or “alcoholics anonymous” or “detoxification” or “neuropsychological rehabilitation” or “occupational therapy” or “physical therapy” or “psychosocial rehabilitation” or “therapeutic social clubs” or “vocational rehabilitation” or “supported employment” or “vocational evaluation” or “work adjustment training” or “relaxation therapy” or “progressive relaxation therapy” or “sex therapy” or “social casework” or “social group work” or “sociotherapy” or “speech therapy” or “treatment guidelines” or “self help techniques” or “self management” or “self instructional training” or “therapeutic social clubs” or “medicinal herbs and plants” or “hypericum perforatum” or “dietary supplements” or “diets” or “nutrition” or “vitamins” or “ascorbic acid” or “choline” or “lecithin” or “folic acid” or “nicotinamide” or “nicotinic acid”) | 465,812
#3 | #1 AND #2 and PT=(journal article) and (ME=(empirical study) or ME=(field study) or ME=(followup study) or ME=(longitudinal study) or ME=(prospective study) or ME=(qualitative study) or ME=(quantitative study) or ME=(retrospective study) or ME=(treatment outcome/clinical trial)), limited to English language and peer-reviewed journals and human population | 1,373

Key: DE subject descriptor; PT publication type; ME methodology; AE age group

Table A3 ERIC search strategies (CSA interface)

Search terms | | Search results
#1 | (“pervasive developmental disorders”) or autism or (“asperger syndrome”) | 6,308
#2 | (DE=(“therapy” or “educational therapy” or “group therapy” or “hearing therapy” or “music therapy” or “occupational therapy” or “physical therapy” or “psychotherapy” or “milieu therapy” or “relaxation training” or “speech therapy” or “therapeutic recreation” or “play therapy” or “art therapy” or “bibliotherapy” or “drug therapy” or “intervention” or “crisis intervention” or “early intervention” or “individualized family service plans” or “prereferral intervention” or “outcomes of treatment” or “rehabilitation” or “special education” or “adapted physical education” or “therapeutic environment” or “Dietetics” or “Food” or “Nutrition”) OR KW=(“therapy” or “therapeutic” or “therapeutics” or “intervention” or “interventions” or “psychotherapy” or “psychotherapeutics”)) | 98,472
#3 | #1 and #2, limited to peer reviewed journals, English only | 770

Key: DE subject descriptor, KW keyword