# Appendixes

Appendix A Exact Search Strings and Results

Appendix B Sample Data Abstraction Forms

Appendix C Evidence Tables

Appendix D List of Excluded Studies

Appendix E List of Peer Reviewers

Appendix F Approach to Categorizing Study Designs

Appendix G Discussion of Recent Systematic Reviews of Therapies for Children with ASDs

Appendix H Quality of the Literature

Appendix I Applicability Summary Tables