# Acknowledgments

We are indebted to a tireless group of colleagues who made this report possible. Each step of systematic reviews draws on the skills and attention of an entire team.

Ms. Rachel Bazan and Mr. Michael Tranchina were our energetic student workers. They spent hours helping to track and file documents, and were always positive and always ready to ensure that the project investigators had what they needed to do their work.

Ms. Ellen Davis and Ms. Cheena Clermont provided invaluable research assistance on this report. Ms. Kathy Lee and Mr. Jeff Seroogy checked tables, formatted tables, and located citations.

Dr. Mark Hartmann brought his extraordinary attention to detail—and his commitment to perfection—to completion of the evidence tables. He spent many, many hours checking and rechecking tables both for formatting and for content. His ability to point out inconsistencies and enhance uniformity was key to ensuring smooth development of the evidence tables.

Ms. Nikki McKoy provided invaluable advice and assistance with formatting and logistics.

Ms. Rachel Walden and Ms. Pauline Alexander are key members of the library science staff. Their support of Ms. Jerome, including their detailed approach to literature searching and data abstraction, was invaluable. Their thoughtful attention to detail in reviewing abstracts and articles for inclusion in the review was a generous gift to the project and to the EPC as a whole.