# Acronyms/Abbreviations

ABA: Applied Behavior Analysis
ABC: Aberrant Behavior Checklist
ABC-C: Aberrant Behavior Checklist-Community
ADHD: Attention Deficit Hyperactivity Disorder
ADI: Autism Diagnostic Interview
ADI-R: Autism Diagnostic Interview-Revised
ADIS: Anxiety Disorders Interview Schedule
ADOS: Autism Diagnostic Observation Schedule
ADOS-G: Autism Diagnostic Observation Schedule-Generic
AHRQ: Agency for Healthcare Research and Quality
AIT: Auditory Integration Training
ASDs: Autism Spectrum Disorders
ASSQ: Autism Spectrum Screening Questionnaire
ATEC: Autism Treatment Evaluation Checklist
Atm: Atmospheres
BAS II: British Abilities Scales-Second Edition
BASC: Behavior Assessment System for Children
CABAS: Comprehensive Application of Behavior Analysis to Schooling
CAM: Complementary and Alternative Medicine
CARS: Childhood Autism Rating Scale
CAST: Childhood Asperger Syndrome Test
CBT: Cognitive Behavioral Therapy
CGI: Clinical Global Impression Scale
CGI-I: Clinical Global Impression-Improvement
CHAT: Checklist of Autism in Toddlers
Cont: Continued
CPEP-R: Chinese Version of the PEP-R
CYBOCS: Child Yale Brown Obsessive Compulsive Scale
CYBOCS-PDD: Children’s Yale-Brown Obsessive Compulsive Scales-Pervasive Developmental Disorders
DH: Donepezil hydrochloride
DMSA: Dimercaptosuccinic Acid
DSM-IV: Diagnostic and Statistical Manual of Mental Disorders-Fourth Edition
DTT: Discrete Trial Training
dx: Diagnosis
EEG: Electroencephalogram
EIBI: Early Intensive Behavioral Intervention
EOWPVT: Expressive One-Word Picture Vocabulary Test
EOWPVT-R: Expressive One-Word Picture Vocabulary Test-Revised
EPC: Evidence-based Practice Center
ERIC: Education Resources Information Center
ESDM: Early Start Denver Model
FSIQ: Full Scale Intelligence Quotient
GARS: Gilliam Autism Rating Scale
GI: Gastrointestinal
HKBABS: Hong Kong Based Adaptive Behavioral Scales
HSQ: Home Situations Questionnaire
IGOH: Oral Human Immunoglobulin
IQ: Intelligence Quotient
kg: kilograms
MASC: Multidimensional Anxiety Scale for Children
mg: milligrams
mg/kg/day: milligrams per kilogram per day
MGIS: Modified Global Impression Scale
MPH: Methylphenidate
n, N: number
NCA: Non Core Autism (PDD-NOS or other early childhood developmental disorder such as specific language disorder)
NR: Not reported
nRCT: Non randomized controlled trial
NS, ns: Not (statistically) Significant
NVIQ: Non-Verbal IQ
P: P value
PCIT: Parent Child Interaction Therapy
PDD: Pervasive Developmental Disorder
PDD-NOS: Pervasive Developmental Disorder-Not Otherwise Specified
PECS: Picture Exchange Communication System
PEP-R: Psycho-educational Profile-Revised
PUFA, PUFAs: Polyunsaturated Fatty Acid
RCT: Randomized Controlled Trial
ROWPVT: Receptive One-Word Picture Vocabulary Test
RPMT: Responsive Education and Prelinguistic Milieu Teaching
RUPP: Research Units on Pediatric Psychopharmacology
SCAS-P: Spence Children’s Anxiety Scale
SCQ: Social Communication Questionnaire
SD: Standard Deviation
SRIs: Serotonin Reuptake Inhibitors
SRS: Social Responsiveness Scale
STAT: Screening Tool for Autism in Two-Year-Olds
SULP: Social Use of Language Programme
SWQ: Social Worries Questionnaire
TEACCH: Treatment and Education of Autistic and Communication related handicapped CHildren
TEP: Technical Expert Panel
UCLA: University of California, Los Angeles
UK: United Kingdom
VABS: Vineland Adaptive Behavior Scale