# Results

## Article Selection Process

Once we identified articles through the electronic database searches, review articles, and bibliographies, we examined abstracts of articles to determine whether studies met our criteria. Two reviewers separately evaluated each abstract for inclusion or exclusion using an Abstract Review Form (Appendix B). If one reviewer concluded that the article could be eligible for the review based on the abstract, we retained it. The group included six physicians (KH, OG, RS, SM, FP, SK), and two senior health services researchers (MM, RJ).

Of the entire group of 2,015 articles, 804 required full-text review. For the full article review, two reviewers read each article and decided whether it met our inclusion criteria, using a Full Text Inclusion/Exclusion form. Reasons for article exclusion are listed in Appendix D.

Figure 2 Disposition of articles for TBI and depression

KQ = key question

*The number of articles addressing key question and those excluded exceed the total number of articles in each category because some of articles fit into multiple exclusion categories or addressed more than one key question.

Figure 2 describes the step-down process by which articles entered and were retained in the review. A rectangle in the top left corner provides the number of articles identified through the literature search (n=1999) and the number through hand searching reference lists (n=16). An arrow leads to a box on the right that indicates that 1,211 articles were excluded at the abstract phase. Moving down the figure on the left are a series of boxes. The first provides the number of full text articles reviewed (n=804). To the right of this is a box with reasons for exclusions as follows: 689 full text articles were excluded; 588 did not address the study questions; 111 were not original research; 111 did not focus on an adult (>16) study population; 256 had sample size less than 50; 16 did not use an appropriate depression assessment tool and 54 were from the grey literature. Finally a set of boxes below the full text reviewed box provides the number of articles available for each key question: 112 were available for Key Question 1; 113 were available for Key Question 2; 9 were available for Key Question 3; 2 were available for Key Question 4 and none were available for Key Questions 5 and 6.

### KQ1 Prevalence of Depression in Traumatic Brain Injury

Understanding the meaning of prevalence estimates requires knowing about both the traumatic brain injury (TBI) population and the method of depression ascertainment. In this section we describe prevalence in the context of the definition of TBI and severity level, as well as the measure of depression used in the research.

#### Prevalence

We sought publications that provided a defined group of individuals with TBI and used a validated measure of depression to assess the proportion of the population who met specified criteria for depression. We excluded reports relying on simple self-report or single screening items. This key question (KQ) focuses on prevalence because prior and existing depression at the time of head injury are difficult to document in order to formally study incidence.

We identified 112 publications30,13–15,31–138 from 79 distinct study populations (see Appendix C, Evidence Table 1). Thirty-eight of the 79 were in the United States, 12 in Canada, 12 in Europe, 9 in Australia, and 8 in other countries (Table 8). The most common sources of study populations were tertiary care centers identifying participants from emergency department, intensive care, and inpatient admissions (n = 33), including those that specifically noted trauma center status (n = 10), and rehabilitation programs (n = 19). Neuropsychology labs, private neuropsychology practices, prisons, veterans’ records, databases, and psychiatric care facilities each contributed three or fewer populations.

Table 8 Characteristics of included TBI and depression studies

| Population Studied
Characteristic | U.S. (n = 38) | Canada (n = 12) | Europe (n = 12) | Other (n = 17) | Total (n = 79)
Assessment of depression:
Cross-sectional | 25 | 9 | 9 | 15 | 58
Prospective | 13 | 3 | 3 | 2 | 21
Setting
Trauma center(s) | 7 | 0 | 0 | 3 | 10
Tertiary care center(s) | 10 | 7 | 9 | 7 | 33
Rehabilitation center(s) | 8 | 2 | 3 | 6 | 19
Psychiatric/specialty center(s) | 2 | 0 | 0 | 0 | 2
Other | 11 | 3 | 0 | 1 | 15
Operational Definition of TBI^*^
CDC Criteria | 1 | 0 | 0 | 0 | 1
WHO Criteria | 1 | 0 | 0 | 0 | 1
ACRM Criteria | 7 | 6 | 0 | 0 | 13
GCS Score | 20 | 5 | 5 | 8 | 38
Self-Report | 3 | 0 | 0 | 1 | 4
Other | 2 | 0 | 6 | 4 | 12
Not Defined | 6 | 1 | 1 | 4 | 12
Depression Tool Used^*^
SCID | 19 | 5 | 1 | 2 | 29
Other structured interview | 1 | 0 | 2 | 1 | 4
MMPI | 2 | 2 | 0 | 0 | 4
HAM-D | 2 | 0 | 2 | 1 | 5
BDI | 7 | 1 | 1 | 4 | 13
CES-D | 7 | 0 | 0 | 1 | 8
HADS | 2 | 0 | 4 | 5 | 11
NFI | 5 | 0 | 0 | 0 | 5
SCL-90 | 2 | 0 | 1 | 1 | 4
Other | 15 | 8 | 11 | 10 | 44

* Inclusive: total is greater than number of studies because some publications used multiple definitions or tools.

Criteria for defining and characterizing those classified as having TBI were varied with more than half of authors (n = 38) using closed head injury in concert with Glasgow Coma Scores (GCS). American Congress of Rehabilitation Medicine criteria were common (n = 13); as were ad hoc operational definitions (n = 12), and failing to clearly define criteria (n = 12). In total, the majority of the literature provides sufficient detail about inclusion and exclusion criteria and TBI definitions to understand and/or replicate the population studied.

Seventy-three percent of studies provided cross-sectional measures of depression, meaning that depression status was assessed at a single point in time after TBI; the balance were prospective with two or more assessment of depression status over time. Structured clinical interviews, done specifically for the research or in the course of standardized clinical care protocols, were the most common means of assessing depression status (n = 29). Among written or administered tools the Beck Depression Inventory (BDI; n = 13), Hospital Anxiety and Depression Scale (HADS; n = 11) and Center for Epidemiologic Studies Depression Scale (CES-D; n = 8), were most common. A wide variety of other measures and customized uses of subscales (n = 62) were also used. Studies often used more than one instrument, reporting different facets of the scores or evaluation. Comparison of diagnostic test characteristics, agreement of classification, and use of expert Structured Clinical Interview for DSM-IV (SCID) as a gold standard for comparisons were rare (see KQ2), while statistical analyses of correlation of scores or relationships of domains were frequent but generally not intended to directly assess clinical utility.

For this report, we have considered the SCID and other formal structured clinical interview protocols that map to the Diagnostic and Statistical Manual of Mental Disorders (DSM) and/or International Classification of Diseases (ICD) codes to be the measures of depression that are most relevant to clinical care. Ideally patients and care providers want to know what proportion of those with TBI may meet clinical criteria for diagnosis and treatment of depression. Among studies that used a SCID or other structured protocol to reach a formal diagnosis of depression, the prevalence of depression after TBI ranged from 12.2 percent66 to 76.7 percent.13 If we focus on the subset of studies with both clearly operationalized criteria for TBI and use of the SCID, the range was 12.2 percent66 to 54.0 percent.109 Across all timeframes and depression measures, in studies with clear TBI definitions, the weighted average for prevalence of depression was 31 percent.

Table 9 summarizes context, size of study, measures, and prevalence of depression among studies with clear definitions of TBI. Appendix C includes a similar summary table for studies that provided less information about TBI criteria. In both sets of studies—those with and without optimal definitions of TBI—the observed prevalences are compatible. In these tables, results are organized by timeframe in which the depression assessment was conducted relative to the injury and by method of assessment. Among those studies with longer term followup, no clear pattern of expected prevalence or natural history emerges:

- Veterans who were hospitalized for TBI approximately 50 years earlier had an 11.2 percent point prevalence of depression, statistically higher than the 8.5 percent among those hospitalized for conditions other than TBI.15
- Followup of another group of veterans at an average of 23 years from TBI found 44 percent met criteria for depression.128
- Assessment of a group with severe TBI at a mean of 14 years from injury was associated with 44.7 percent prevalence.31
- Among studies with assessments 5 to 10 years from TBI, reported prevalences were 9.8 percent,105 23 percent,103 29.5 percent,57 and 70 percent.112
- Those with assessments three to 5 years from TBI, reported prevalences from 34 to 77 percent.13,32,38,55,65,85,137

Table 9 Prevalence of depression by timing of assessment

Author Year Country Setting | N with TBI, (% with Depression Measure) | GCS Score | Assessment Method (mean score) | Prevalence %
Unspecified time from injury
Evans et al.58 2005 U.S. Rehabilitation center | 96 (100) | 3–15 | CES-D (NR) | 54.0
Hoge et al.30 2008 U.S. Other | 384 (95.8) | CDC/WHO criteria | PHQ (NR) | 13.0
Kant et al.107 1998 U.S. Psychiatric/specialty center | 83 (100) | 3–15 | BDI (18.03) AES (38.84) | 10.8 60.2
Ruocco et al.37 2007 U.S. Other | 231 (100) | 13–15 | MCMI-III Depressive (46.62) MCMI-III Major Depression (56.70) | 16.9 30.3
< 3 months since injury
Gomez-Hernandez et al.108 1997 Spain Tertiary care center | 65 (100) | 3–15 | SCID | 35.4
Jorge et al.14,111,114–117 1993 U.S. Trauma center | 66 (100) | 3–15 | SCID | 28.8
Jorge et al.72,76 2004 U.S. Other | 91 (81.3) | 12.3 (mean) | SCID | 20.2
McCauley et al.62–63 2005 U.S. Trauma center | 340 (100) | 9–15 | SCID | 15.0
McCauley et al.83 2001 U.S. Tertiary care center | 115 (100) | 9–15 | SCID CES-D (22.5) VAS-D (40.1) | 21.7 NR NR
Rao et al.136 2009 U.S. Rehabilitation centers | 107 (62.6) | 3–15 | SCID | 11.9
Rapoport et al.77,79 2003 Canada Tertiary care center | 210 (100) | 13–15 | SCID | 16.7
Bombardier et al.138 2010 U.S. Trauma center | 559 (51.7) | 3–15 | PHQ-9 | 31.1 (1 mo)
Bombardier et al.138 2010 U.S. Trauma center | 559 (70.0) | 3–15 | PHQ-9 | 24.7 (2 mos)
Kashluba et al.54 2006 Canada Tertiary care centers | 110 (100) | 13–15 | PCL (NR) | 40.0
Rapoport et al.82 2002 Canada Tertiary care center | 323 (87.3) | 3–15 | NRS (NR) | Mild/Mod: 34.3
Sherer et al.40 2007 U.S. Rehabilitation center | 69 (100) | 8.0 (mean) | CES-D (11.6) | 31.9
3 to 6 months since injury
Brown et al.68 2004 U.S. Trauma center | 135 (100) | 14.5 (mean) | SCID | 16.3^*^
Bryant et al.134 2010 Australia Trauma centers | 437 (86.3) | 13–15 | MINI | 17.9
Gomez-Hernandez et al.108 1997 Spain Tertiary care center | 65 (73.8) | 3–15 | SCID | 37.5
Herrmann et al.135 2009 Canada Tertiary care center | 200 (100) | ACRM criteria | SCID | 48.0
Jorge et al.14,111,115–117 1993 U.S. Trauma center | 66 (81.8) | 3–15 | SCID | 29.6
Jorge et al.72,76 2004 U.S. Tertiary care centers | 91 (81.3) | 12.3 (mean) | SCID | 32.4
Levin et al.84 2001 U.S. Trauma center | 69 (100) | 9–15 | SCID CES-D (22.14) VAS-D (40.79) | 17.4 NR NR
Bombardier et al.138 2010 U.S. Trauma center | 559 (73.0) | 3–15 | PHQ-9 | 24.5 (3 mos)
Bombardier et al.138 2010 U.S. Trauma center | 559 (74.2) | 3–15 | PHQ-9 | 21.9 (4 mos)
Bombardier et al.138 2010 U.S. Trauma center | 559 (75.7) | 3–15 | PHQ-9 | 22.9 (5 mos)
Dunlop et al.119 1991 U.S. Other | 68 (100) | 9.2 (mean) | NRS (NR) | 50.0
Kashluba et al.54 2006 Canada Tertiary care centers | 110 (100) | 13–15 | PCL (NR) | 39.1
McCauley et al.86 2001 U.S. Trauma centers | 210 (100) | ACRM criteria | NRS-R (NR) | 51.0
Rapoport et al.82 2002 Canada Tertiary care center | 323 (87) | 3–15 | NRS (NR) | Severe: 48.9
6 to 12 months since injury
Chamelian et al.50,67 2004 Canada Tertiary care center | 90 (100) | 9–15 | SCID GHQ (0.85) | 12.9 NR
Gomez-Hernandez et al.108 1997 Spain Tertiary care center | 65 (64.6) | 3–15 | SCID | 38.1 (6 mos)
Gomez-Hernandez et al.108 1997 Spain Tertiary care center | 65 (66.2) | 3–15 | SCID | 32.6 (9 mos)
Jorge et al.14,111,114–117 1993 U.S. Trauma center | 66 (65.2) | 3–15 | SCID | 25.6
Jorge et al.72,76 2004 U.S. Tertiary care centers | 91 (100) | 12.3 (mean) | SCID | 40.5
Mooney et al.87 2001 U.S. Rehabilitation center | 80 (100) | 13–15 | SCID | 44.0
Rapoport et al.66 2005 Canada Tertiary care center | 74 (100) | 9–15 | SCID | 28.4
Rapoport et al.49,52 2006 Canada Rehabilitation center | 69 (71) | 9–15 | SCID Major | 12.2 18.8
Bay et al.44,80 2002/2007 U.S. Tertiary care center | 75 (100) | >8 | CES-D (20.5) NFI (30.7) | 64.0 14.7
Bombardier et al.138 2010 U.S. Trauma center | 559 (77.3) | 3–15 | PHQ-9 | 20.8 (6 mos)
Bombardier et al.138 2010 U.S. Trauma center | 559 (68.9) | 3–15 | PHQ-9 | 24.2 (8 mos)
Bombardier et al.138 2010 U.S. Trauma center | 559 (64.0) | 3–15 | PHQ-9 | 27.1 (10 mos)
Bryant et al.90 2001 Australia Rehabilitation center | 96 (100) | 8.0 (mean) | BDI (16.5) | 45.8
Dunlop et al.119 1991 U.S. Other | 68 (100) | 9.2 (mean) | NRS (NR) | 28.0
Ghaffar et al.47 2006 Canada Tertiary care centers | 191 (63.9) | 14.9 (mean) | GHQ | 28.7
Hawley and Joseph33 2008 U.K. Rehabilitation centers | 563 (7.2) | 3–15 | HADS (NR) | 20.5
Kersel et al.45,88 2001 New Zealand Tertiary care center | 69 (84) | <9 | BDI (NR) | 24.0
McCleary et al.99–101 1998 U.S. Tertiary care center | 105 (100) | 3–15 | SCL-90 (NR) NRS (NR) | 24.4 33.0
Ziino and Ponsford125 2006 Australia | 46 (100) | 3–15 | HADS (NR) | 39.1
>12 months since injury
Al-Adawi et al.41 2007 Oman Tertiary care center | 68 (100) | 3–15 | CIDI (NR) HADS (NR) | 57.4 19.1
Ashman et al.70–71 2004 U.S. Tertiary care center | 188 (100) | ACRM criteria | SCID | 35.0 (T1: 3 mos – 4 yrs)
Ashman et al.70–71 2004 U.S. Tertiary care center | 188 (100) | ACRM criteria | SCID | 24.0 (12 mos after T1)
Ashman et al.70–71 2004 U.S. Tertiary care center | 188 (44.1) | ACRM criteria | SCID | 21.0 (24 mos after T1)
Bryant et al.134 2010 Australia Trauma centers | 437 (73.5) | 13–15 | MINI | 17.4
Fann et al.109 1995 U.S. Rehabilitation center | 50 (100) | 3–15 | SCID | 54.0
Gomez-Hernandez et al.108 1997 Spain Tertiary care center | 65 (56.9) | 3–15 | SCID | 27.0
Homaifar et al.128 2009 U.S. Tertiary care center | 52 (100) | 3–15 | SCID | 44.2
Huang et al59 2005 U.S. Tertiary care center | 59 (100) | 3–15 | SCID ZDS (39.6) | 13.6 16.9
Jorge et al.14,111,114–117 1993 U.S. Trauma center | 66 (65.2) | 3–15 | SCID | 25.6
Kennedy et al.57 2005 U.S. Other | 78 (30) | 9.3 (mean) | SCID | 30.0
Rapoport et al.49,52 2006 Canada Rehabilitation center | 77 (59.7) | 9–15 | SCID | 12.2
Whelan-Goodinson et al.32,130 2008 Australia Tertiary care center | 100 (100) | <15 | SCID | 34.0
Bay and Donders36 2008 U.S. Rehabilitation center | 84 (100) | 9–15 | NFI-D (31.71) | 58.0
Bombardier et al.138 2010 U.S. Trauma center | 559 (65.3) | 3–15 | PHQ-9 | 23.3
Chiu et al.46 2006 Taiwan Tertiary care centers | 199 (100) | 3–15 | CES-D (NR) | 23.9
Deb et al.95–96,42 1999 U.K. Tertiary care center | 196 (83.7) | 3–15 | SCAN (NR) Behavior checklist (NR) | 12.8 19.5
Franulic et al.73 2004 Chile Tertiary care center | 71 (100) | 12.5 (mean) | HAMD (NR) | 42.3
Frenisy et al.48 2006 France Tertiary care center | 25 (100) | <8 | NRS-R (NR) SCL 90-R (9.72) | 76.0 NR
Gagnon et al.55 2006 Canada Rehabilitation center | 30 (100) | 3–13 | BDI (10.47) | 50.0
Hawthorne et al.133 2009 Australia Trauma center | 66 (100) | 3–15 | HADS | 22.7
Keiski et al.39 2007 Canada Other | 53 (81.1) | 13–15 | PAI (NR) | 55.8
Kersel et al.45,88 2001 New Zealand Tertiary care center | 69 (84) | <9 | BDI (NR) | 24.1
Lima et al.35 2008 Brazil Tertiary care center | 50 (72) | 13–15 | HADS (NR) | 25.0
McCleary et al.99–101 1998 U.S. Tertiary care center | 105 (100) | 3–15 | SCL-90 (NR) NRS (NR) | 20.0 33.3
Mooney et al.60,87 2005 U.S. Tertiary care center | 67 (100) | 13–15 | BDI-II (22.03) | 61.2
Peleg et al.132 2009 Israel Rehabilitation centers | 65 (100) | 3–15 | BDI (19.3) | 73.9
Ponsford and Schönberger137 2010 Australia Tertiary care center | 301 (100) | 3–15 | HADS (NR) | 45.0 (24 mos)
Ponsford and Schönberger137 2010 Australia Tertiary care center | 266 (100) | 3–15 | HADS (NR) | 44.0 (60 mos)
Popovic et al.65 2004 Serbia Tertiary care center | 67 (64.2) | 3–13 | ZDS (41.2) | 46.3
Seel et al.74,78 2003 U.S. Rehabilitation centers | 666 (100) | 8.6 (mean) | NFI-D (NR) | 27.0
Sherman et al.93 2000 Canada Other | 175 (100) | ACRM criteria | MMPI (NR) | 33.0
Stalnacke38 2007 Sweden Tertiary care center | 201 (81) | 13–15 | BDI (6.88) Mild to Mod Mod to Severe | 25.0 15.0

Among the studies that included comparison groups, 28 reported higher prevalence of depression among those with TBI than those without.30,13,15,35,43,49,53–55,72,75,83–84,92,97–99,101,112,125,131,133–134,125,129,131,133–134 Another reported higher mean depression scores among the TBI group (Beck 5-point scale: 5.5 ± 5.4) compared to controls (2.7 ± 3.1, p = 0.003).129 Exceptions included: a psychiatric population control group with an equivalent proportion having depression (30 percent);37 patients with multiple serious injuries from trauma that did not include TBI compared to patients with TBI in which both groups had 76 percent with depression;48 a prospective cohort in Australia in which those with mild TBI were compared to others hospitalized for similar length trauma admissions without TBI,134 and a matched control group from the same district in Finland in which both groups had approximately 6 percent prevalence.61 In no instance was the comparison group significantly more affected by depression.

No evidence suggests that study setting, country, or size of study population influences the observed prevalence. As expected, smaller studies report a wider range or prevalence and estimates from larger studies are closer to the mean estimates (Figure 3).

Figure 3 Relationship of study size to observed prevalence of depression

Figure 3 is a graph that compares the sample size for each included study on the horizontal axis to the prevalence identified in that study on the vertical axis. Each study is indicated by a gray diamond and is placed at the appropriate place to indicate the study size and the prevalence reported in the study. Prevalence ranges from 10 percent to nearly 80 percent with the greatest range in the smaller studies. The seven largest studies (more than 250 participants) provide prevalence estimates ranging from 10 percent to slightly more than 40 percent.

Data are sparse to assess whether severity of injury influences risk of depression. Using structured interviews, the overall prevalence of depression was 20.3 percent in those with mild or mild/moderate TBI compared to 32.5 percent in studies that enrolled or followed up populations of all severity. Too few studies isolate a sufficient number of those with mild TBI compared to those with moderate and/or severe injuries to make valid severity-based estimates of prevalence. In the sole model that assessed GCS scores, coma length, and duration of post-traumatic amnesia, none of the factors were associated with depression or its severity.131 Another group using the Injury Severity Score also found no association between severity and prevalence of depression.134 Likewise, stratification of prevalence by explanatory factors such as age, gender, area of brain injured, or mechanism of injury is not possible within the current body of literature.

#### Risk Factors

Fourteen studies in 13 distinct study populations report results from multivariate models to identify predictors or risk factors for depression after TBI.14–15,36,51,63,77,91,112,116,131–134,138 Age was reported in a large United States cohort (n = 559), to be an independent risk factor for depression among both those without prior depression and those with prior episodes. In this study, which reflects the full spectrum of severity of TBI, risk decreased with increasing age, such that those age 60 and older were at lowest risk.138 In another study aiming at predicting risk, when age was grouped with other factors, the combination of older age at injury, CT scan with documented intracranial lesion, and higher 1-week CES-D scores, were sensitive (93 percent) though not specific (62 percent) for identifying those with mild TBI who were depressed by 3 months after their injury.63 One group has found that women have higher risk (relative risk [RR] = 1.27; 95 percent confidence interval [CI]: 1.07, 1.52) of new but not recurrent depression after TBI after adjusting for other risk factors.138

History of alcohol and substance abuse increase risk.15,77,138 Pain, involvement in litigation related to the injury, and perceived stress have been reported as risk factors among those entering rehabilitation care and in prospective cohorts.36,134 Psychosocial supports were often described in this literature, and data from caregivers, partners, and family members were common. However, few models incorporated social support items. One group reported that “availability of a confidant” reduced risk of depression,91 and another that years married were inversely related to risk, while presence and degree of cognitive disability, motor disability, and social aggression elevated risk.112 Concepts related to resilience or personality traits have not been widely investigated but scores on the Adult Hope Scale (p < 0.005) and the Life Orientation Test-Revised (p < 0.05), a measure of dispositional optimism, are both found contribute independently to predicting depression and its severity as measured by the BDI in a small Israeli study (n = 65).132 History of depression has been documented as a substantive risk for having depression at followup (RR = 1.54; 95 percent CI: 1.31, 1.82), as was depression at the time of the injury (RR = 1.62; 95 percent CI: 1.37, 1.91).138

A cluster of reports were focused on investigating whether incorporating information about the area of the brain affected by the injury helped identify those at highest risk. Imaging research about the areas of the brain injured and the relationship to depression risk has inconsistent results. In aggregate for all those with TBI, onset of major depression within 3 months of injury has been reported to be sevenfold as common (95 percent CI: 1.36 to 43.48) among those with abnormal CT scan results after injury compared with normal imaging.63 Focusing on locations of injury, Jorge and colleagues14,116 have replicated their findings in several CT-based studies that left anterior lesions involving the left dorsolateral frontal cortex and/or left basal ganglia are associated with increased risk of acute depression (p = 0.006) when injury location is assessed in multivariate regression models. They also note that frontal lesions, whether left, right, or bilateral, are associated with decreased risk of acute depression (p = 0.04). In contrast delayed-onset major depression was not associated with lesion location. In a subanalysis of depression types, depression alone was related to left hemisphere injury (p = 0.003), while depression associated with anxiety was more common among those with right hemisphere injury (p = 0.003). A specific assessment of the presence or absence of contusions found the type of injury was not predictive and that depression was somewhat more common among those with contusions (71 percent) than among those without (62 percent). Using MRI near the time of injury, the findings from CT studies are not supported and the only lesion type to emerge as a significant predictor was the protective effect of temporal lesions compared to other injury locations (p = 0.028).51 Study size and timing in relation make this literature more exploratory than conclusive in beginning to understand the relationship between pathophysiology related to the brain injury and risk and timing of onset of depression. In a study of political prisoners, up to 50 years after injury, TBI-associated cerebral cortical thinning in the left superior frontal and bilateral superior temporal cortex, as assessed by MRI, were associated with depression, and similar effects were not seen in prisoners without a history of TBI with respect to depression risk.131

Overall, the quality of studies that provided prevalence estimates was 13 good quality (11.6 percent), 72 fair quality (64.3 percent), and 27 poor quality (24.1 percent). Many of these studies were not explicitly designed to assess prevalence and are of higher quality for their intended aims. Overall, the strength of the evidence to estimate prevalence is moderate. Factors included in the assessment were varied methods for defining TBI and depression, small study populations, and predominance of populations such as those in tertiary care referral centers, trauma centers, and rehabilitation programs that cannot represent the entire denominator of individuals with head injury in the United States. Experts suggest this shortcoming relates to a lack of funding resources to identify and follow large cohorts of varied injury severity and mechanism over time. However, despite these limitations, no evidence suggests depression prevalence is not elevated in general TBI populations.

### KQ2 Screening for Depression After TBI

After answering the question of prevalence of depression in the patient with TBI, the next step is to identify the timing of screening for depression, which screening tools to utilize, and the optimal setting for screening.

In all timeframes and with all measures, depression is common (Table 10). No distinct trend is apparent to suggest a peak time of enhanced risk or a related priority window for screening. In general, the proportion of those diagnosed as depressed through structured clinical interviews is lower than standardized instruments. This would be expected, as the majority of tools are designed to be more sensitive than specific in order not to miss potential cases. Around 1 year and beyond, both categories of assessments converge around 33 percent.

Table 10 Prevalence of depression by method of assessment, setting, and time from injury

| Structured Clinical Interview Protocols | | | | | Other Validated Depression Assessment Tools
| Time from Injury to Assessment | | | | | Time from Injury to Assessment
| 0–3 mos | 3–6 mos | 6–12 mos | 12+ mos | All times | 0–3 mos | 3–6 mos | 6–12 mos | 12+ mos | All times
All study settings and TBI severity
Studies with data (n) | 9 | 7 | 6 | 17 | 39 | 4 | 3 | 13 | 34 | 54
Prevalence (%) | 18.3 | 26.8 | 31.9 | 32.5 | 27.4 | 34.3 | 45.7 | 31.8 | 32.8 | 33.3
Tertiary care populations
Studies with data (n) | 2 | 1 | 3 | 8 | 14 | 2 | 2 | 2 | 11 | 17
Prevalence (%) | 18.5 | 48.0 | 28.3 | 38.7 | 34.5 | 36.8 | 44.6 | 35.5 | 28.2 | 32.7
Trauma center populations
Studies with data (n) | 3 | 5 | 2 | 4 | 14 | 0 | 0 | 5 | 8 | 13
Prevalence (%) | 19.8 | 22.4 | 31.8 | 18.5 | 20.1 | 0 | 0 | 30.1 | 38.3 | 34.5
Rehabilitation centers
Studies with data (n) | 2 | 0 | 0 | 3 | 5 | 2 | 0 | 6 | 6 | 14
Prevalence (%) | 14.0 | 0 | 0 | 42.5 | 32.0 | 29.2 | 0 | 33.8 | 37.2 | 35.5
All levels of TBI severity
Studies with data (n) | 4 | 3 | 3 | 8 | 18 | 1 | 1 | 6 | 10 | 18
Prevalence (%) | 23.9 | 33.3 | 35.9 | 35.9 | 32.5 | 31.9 | 48.9 | 29.9 | 28.9 | 30.9
Populations with mild and/or mild/moderate TBI by Glasgow Coma Scale^*^
Studies with data (n) | 4 | 4 | 2 | 2 | 12 | 1 | 0 | 1 | 4 | 6
Prevalence (%) | 16.6 | 25.4 | 21.3 | 16.8 | 20.3 | 34.3 | 0 | 28.7 | 45.1 | 39.1
Populations with moderate and/or severe TBI by Glasgow Coma Scale^*^
Studies with data (n) | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 2 | 5 | 8
Prevalence (%) | 0 | 0 | 0 | 0 | 0 | 0 | 50.0 | 37.7 | 30.1 | 32.5

* Number of studies reporting data for those with mild TBI alone is insufficient to report weighted means.

This review cannot distinguish between whether this suggests that other tools “over-detect” depression relative to structured clinical interviews or whether differences in study design and population create the observed effect. We also cannot distinguish if features unique to a population with TBI make clinical diagnosis more challenging, or whether evaluators in clinical settings are less likely to classify a patient as depressed early after trauma, deferring definitive diagnosis until later in followup as other sequelae of injury subside or stabilize.

As presented in Table 10, prevalence of depression is higher in all timeframes than would be expected from population-based estimates. These estimates may center around 30 percent in all windows for several reasons. In one scenario, prevalence reaches this level quickly; depression is under-recognized or poorly responsive to treatment; and overall, the same individuals are affected over time and therefore available in each time window to be detected. In another scenario, there could be an initial wave of “reactive” depression that resolves in some individuals such that later timeframes reflect continued symptoms in some and new onset of depression in others. In this scenario, individuals are moving in and out of the “case” group over time but the average proportion at any one time approaches one-third.

Overall, the quality of studies that provide information to assess when to screen was 13 good quality (11.5 percent), 73 fair quality (64.6 percent), and 27 poor quality (23.9 percent). The strength of the body of evidence is low for selecting time and setting for screening. Deficits relate to the high proportion of the literature that is cross-sectional so that natural history information cannot be provided, and the small proportion of studies that are prospective having, as a group, relatively few followup intervals. From an ethics perspective, this uncertainty suggests we are obligated to recognize that those with TBI likely have elevated risk of depression and to screen frequently until evidence becomes available to better target timing of evaluations or to confirm that risk is elevated and stays elevated relative to the general population.

Overall, the quality of studies that provide information comparing tools is poor. While many studies evaluate psychometric properties and validation of tools and subscales, few examine the diagnostic test characteristics of tools for clinical use in comparison to a gold standard such as the SCID. Given that TBI is relatively common and that psychiatric and psychological evaluation services can be challenging to access, there would be substantial value in understanding which tools perform best in selecting those individuals most likely to need treatment while still retaining a high negative predictive value so that cases are not missed. Thus, the strength of the body of evidence is insufficient for selecting method of screening.

Table 11 Validity of tools to diagnose depression after TBI

Author, Year Country Setting | Study Design N | Comparison and measures | Outcomes
Sliwinski et al.103 1998 US Other | Cross-sectional N=100 | - BDI vs SCID; - Validity measures, including sensitivity and specificity | - Correlation between the SCID and BDI was 0.30, p<0.05; - With specificity set at 0.80, the BDI correctly identified 36% of individuals diagnosed with depression via the SCID; - With specificity set at 0.90, only 20% were correctly classified as depressed; - A modified (six item) BDI was more strongly correlated with DSM-IV diagnosis (r=0.40, p<0.05), and sensitivity increased to 48% at 80% specificity and to 32% at 90% specificity
Homaifar et al.128 2009 US Tertiary care center | Cross-sectional N=52 | - BDI-II vs SCID; - Validity measures included sensitivity, specificity and ROC analysis | - Maximum sensitivity (87%) and specificity (79%) were achieved using a BDI cutoff of 19 for those with mild TBI and 35 for those with moderate or severe TBI; - A BDI score of 6 or higher produced 100% sensitivity for those with mild TBI, while a score of 23 or higher produced 100% sensitivity for those with moderate or severe TBI; - At 100% sensitivity, specificity decreased to 59%
Fann et al.139 2005 US Trauma center | Prospective cohort N=135 | - PHQ-9 vs SCID; - Validity measures included sensitivity, specificity, PPV and NPV; - ROC analysis identified optimal scoring algorithm | - Various scoring algorithms were used with the PHQ-9; - “Optimal” algorithm has sensitivity 0.93, specificity 0.89, PPV 0.63 and NPV 0.99.
Whelan- Goodinson et al.130 2009 Australia Tertiary care center | Cross-sectional N=100 | - HADS vs SCID; - Validity measures included sensitivity, specificity, PPV, NPV and ROC analysis | - The manual-defined HADS cutoff of 7/8 produced a sensitivity of 62% and a specificity of 92% as compared with the SCID; - The PPV for depression given a cutoff of 7/8 was 81%, while a more conservative cutoff of 12/13 produces a PPV of 100%; - The NPV for depression given a cutoff of 7/8 was 82%
Al-Adawi et al. 2007^41^ Oman Tertiary care center | Cross-sectional N=68 | - HADS vs CIDI (structured clinical interview for ICD-10 diagnosis); - Validity measures included sensitivity, specificity and ROC analysis | - Sensitivity of the depression subscale of HADS to identify patients considered depressed by clinical interview was 33.3%. Specificity was 100% (i.e., no false positives).; - ROC analysis suggested that sensitivity can be increased with lower HADS cutoff; - An “optimal” cutoff off of 4 produced a sensitivity of 53.8% and specificity of 75.9%

Five studies assessed the ability of various tools to screen for depression in individuals with TBI relative to a structured clinical interview, which is accepted as the gold standard for diagnosing depression (Table 11). Three of the studies were conducted in the United States, one at a trauma center,139 one in the community,103 and one in a tertiary care center.128 The community-based study was an analysis of individuals participating in a larger quality of life study focused on community integration of individuals with TBI. One study each was conducted in Oman140 and in Australia,130 both at tertiary care centers. The U.S. and Australian studies used as their gold standard the SCID, based on DSM-IV criteria, while the Oman study used the Composite International Diagnostic Interview (also a structured clinical interview) that is based on ICD-10 criteria for diagnosis. Differences in the reference and index tools preclude synthesis so the studies are described separately below. In their study of the BDI’s ability to correctly identify depressed individuals, Sliwinski and colleagues selected 100 individuals randomly from a larger pool of 433 participating in a quality of life study. All participants had a brain injury that had occurred at least 1 year prior, were between the ages of 18 and 65, and were able to engage in a three to four hour interview. All participants were given both a SCID and a BDI, and sensitivity and specificity calculations were used to assess the ability of the BDI to identify the depressed individuals. Setting specificity at either 80 percent or 90 percent (reflecting the proportion of nondepressed individuals correctly classified as nondepressed), they found low sensitivities (proportion of truly depressed individuals identified by the tool) of 36 percent and 20 percent, despite a statistically significant correlation (albeit low) between the tools of 0.30. After modifying the BDI to include six items that best discriminated between depressed and nondepressed individuals, sensitivity increased slightly but did not exceed 48 percent. Similarly, Homaifar and colleagues studied the validity of the BDI-II, again comparing it to the SCID, in 72 veterans. Of particular importance, this analysis identified different BDI-II cutoffs to maximize validity of the tool, depending on severity of the TBI. In a Receiver Operating Characteristic (ROC) analysis, maximum sensitivity of 87 percent and specificity of 79 percent were obtained with cutoffs of 19 for participants with mild TBI, and 35 for those with moderate or severe TBI.

Fann and colleagues recruited participants from a level one trauma center, with head injuries with a GCS score of less than or equal to 12. Participants were recruited prior to discharge and assessed every month for 6 months and then at 8, 10, and 12 months following injury. Participants were initially given the Patient Health Questionnaire-9 (PHQ-9) over the phone and invited to complete a SCID only if their PHQ-9 score met criteria for possible depression, thus restricting the analysis to a population with fairly high likelihood of depression. The investigators then assessed the ability of various algorithms for scoring the PHQ-9 to identify individuals with depression, using a ROC analysis to find the optimal criteria. The best algorithm, based on maximizing both sensitivity and specificity, resulted in a positive predictive value of 0.63 and a negative predictive value of 0.99. Sensitivity for this algorithm was 0.93 (0.74–1.00), and specificity was 0.89 (0.82–0.94).

Two studies assessed the HADS, both at tertiary care centers. Al-Adawi and colleagues studied 68 consecutive patients at a tertiary care center in Oman who had suffered TBIs, excluding individuals with a preinjury psychiatric condition or other neurological history. They used a structured clinical interview based on the ICD-10 criteria for diagnosis as the gold standard, and assessed the ability of the HADS to correctly identify depressed individuals. Depressive disorder was diagnosed with clinical interview in 57.4 percent of the participants. Using the HADS subscale as recommended resulted in a low sensitivity of 33.3 percent and 100 percent specificity. A lower cutoff of 4 was identified as optimal in a ROC analysis, providing a sensitivity and specificity of 53.8 percent and 75.9 percent, respectively. However, in a similar study conducted in Australia,130 the manual defined cutoff (7/8) resulted in greater sensitivity (62 percent) and slightly lower specificity (92 percent). Nonetheless, this study also supported the use of a more conservative cutoff of 12/13 if the goal is to achieve higher positive predictive value.

Huang and colleagues conducted SCIDs and the Zung depression scale on 70 consecutive patients from a physical rehabilitation hospital but provide no diagnostic test characteristics by which to assess the results.59

With only five studies that included test characteristics available, each using a different screening tool, there is insufficient evidence to determine whether tools validated in other populations for screening depression appropriately identify individuals with depression after a TBI. Several additional studies were identified that compared various screening tools against one another, but none of these conducted a clinical interview to diagnose depression as a comparison.44,74,78,121 In the absence of a clinical diagnosis, it is difficult to assess the utility of these tools for identifying correctly depressed individuals. However, Bay and colleagues did use an expert consensus process to select subscale domains of three screening tools (Neurobehavioral Functioning Index, Profile of Mood States-Depression, CES-D) that correspond to the DSM-IV criteria for major depressive episode, and then found that the three tools were highly correlated (r > 0.80) in their identification of depressed individuals. Nonetheless, SCIDs were not actually done in the study.

This area of research represents a significant gap in the current literature. Given the wide range, and potentially high prevalence of depression after TBI, effective approaches to screening and diagnosis that can be deployed in large populations are needed. As studies are conducted to establish the prevalence of depression, substudies could be conducted focusing on establishing or comparing the validity and reliability of screening tools for this population.

### KQ3 Prevalence of Concomitant Psychiatric Conditions

This section presents the results of our literature search and findings about the prevalence of concomitant psychiatric conditions in patients who develop depression after incurring a traumatic brain injury. We reviewed seven papers from six studies, of which all seven were of fair quality.

Concomitant psychiatric conditions that we included for review included: post-traumatic stress disorder (PTSD), other anxiety disorders, substance abuse, irritability/aggression, and any other named Axis I or Axis II disorders.

#### Content of the Literature

We identified nine studies14,70,72,104,109,111,123,130,138 from eight populations that reported prevalence of concomitant psychiatric conditions within the population of depressed TBI patients,14,109,111,130 or compared rates of comorbid conditions in those with and without depression.70,72,104,123,138 Papers that reported the overall prevalence of psychiatric conditions other than depression among the overall population of TBI patients with no data on their association with depression were excluded for this key question.

Study designs of the eight studies (one study was represented in two papers) included five prospective cohorts,14,70,72,111,123,138 one retrospective cohort,104 and two cross-sectional studies.109,130 Seven studies were conducted in the United States. One was conducted in Australia.130 One was conducted at an academic medical center;70 one at a rehabilitation center;109 one in the community;104 one at two hospitals within the same state;72 one at a tertiary care center;130 and three at trauma centers.14,111,123–138 The most common condition studied in combination with depression was anxiety, which was assessed in six studies.14,72,104,109,130,138 Depression was diagnosed via clinical interview in most of the studies.14,70,72,104,109,111,130,138

#### Summary of the Literature on Concomitant Psychiatric Conditions

The included studies reported relatively high rates of concomitant psychiatric conditions (8 to 93 percent of depressed participants had some concomitant condition), but because few presented these data separately for the depressed and nondepressed groups, few conclusions related specifically to this key question can be drawn. Nonetheless, anxiety appeared to be the most common comorbid condition. In the one study that compared rates of comorbid anxiety in patients with and without depression, it was significantly more common in the depressed group (76.7 percent versus 20.4 percent, p<0.001).72

The four studies that explicitly compare rates of concomitant psychiatric conditions in depressed and nondepressed patients are most useful for answering this key question.

The recruitment phase of a clinical trial for sertraline to treat major depressive disorder (MDD) was described in the largest study, and included 1-year followup of 599 participants, all of whom had GCS scores of ≤12.^138^ Participants were enrolled from among 1,000 potentially eligible patients in a U.S. trauma center and were contacted monthly for months 1 through 6, and then at 8, 10, and 12 months to obtain information on depression status and other psychiatric conditions. Depression was assessed with a structured interview based on the PHQ-9, and assessment for anxiety disorders also used modules of the PHQ. The 1-year cumulative incidence of MDD in this population was 53.1 percent. During this first year following injury, individuals with major depressive disorder had substantially higher rates of a concomitant anxiety disorder than did participants without MDD (60 percent vs. 7 percent: RR, 8.77; 95 percent CI, 5.56 –13.83).

In the second study,123 patients who were hospitalized with TBI of GCS severity ≤12 were assessed 1 to 6 months postinjury. Attempts were made to contact each patient monthly, but not all patients were reached every month. The overall cumulative incidence of both depression (per the PHQ-9) and PTSD (per the PTSD Checklist-Civilian [PCL-C]) were calculated. While the overall incidence of PTSD was 11.3 percent for the cohort, the rate was 37 percent among the 27 individuals who also experienced depression, compared with none among those who did not. No other studies directly compared the proportion of depressed patients with and without PTSD.

Anxiety and aggression were measured in patients participating in a second prospective cohort in which participants were consecutively admitted patients at two hospitals.72 The study compared outcomes among patients with closed head injury to those with multiple trauma but no central nervous system involvement. Among the 91 TBI patients, 68 had sustained their injuries in a motor vehicle accident. Patients were followed up at 3, 6, and 12 months, at which time depression was assessed using a clinical interview and the HADS, and aggressive behavior was assessed with the Overt Aggression Scale. About one-third (33 percent) of patients had major depressive disorder (mood disorder with major depressive features). Over the course of followup, 23 of 30 (77 percent) of patients with major depressive disorder also had anxiety, compared with 9 of 44 (20.4 percent) of nondepressed patients (note: total N does not add up due to lack of complete data). Of note, PTSD was included with anxiety in this study and was the defining psychiatric feature for 7 of the 23 patients diagnosed with anxiety. Similarly, 17 of 30 (56.7 percent) depressed patients exhibited aggression, compared to 10 of 44 (22.7 percent) nondepressed patients.

A cohort of 188 individuals with TBI who were enrolled in a larger, third study of mood disorders and psychosocial functioning after TBI was assessed twice over 12 months for depression and other psychiatric comorbidities.70–71 The participants were all living in the community and had sustained their head injury within the past 5 years. They were recruited via telephone, and those who agreed to participate were assessed in person at study entry and 12 months later. In part, this study focused not only on the presence or absence of depression and other psychiatric conditions, but on the timing of the depression as it related to the presence of co-occurring psychiatric disorders. Therefore, individuals were subdivided into four groups for analysis: no depression at either time point, resolved depression (present at study entry but not at 12 months), late-onset depression (present at 12 months but not at study entry) and chronic depression (present at study entry and 12 months). At study entry, co-occurring psychiatric conditions were most frequent among those individuals who would have late-onset depression (74 percent of late onset patients) and lowest among those in the chronic depression group (26 percent). At reassessment, the presence of psychiatric conditions had increased in every group except those never diagnosed with depression, although in this group more than half of the individuals had depression at both time points. Among the psychiatric conditions examined, anxiety was most common at both study entry and 12 months (19 percent and 16 percent, respectively). Psychiatric diagnoses before the TBI itself were common across all groups (56 percent of the overall population) with no statistically significant differences between groups.

The other two papers14,111 representing one study that used a prospective cohort design did not provide a measure of the incidence of psychiatric comorbidity in the nondepressed group. The authors report that 41 percent and 8 percent of depressed TBI patients had anxiety and bipolar disorder, respectively.14,111

In other study designs, a retrospective cohort of community-dwelling individuals with TBI at least 1 year prior to interview104 found that among pairs of concomitant psychiatric conditions, depression and anxiety combined was most common (25 percent), and that individuals with a pre-TBI Axis I diagnosis were most likely to experience coexisting diagnoses post-TBI (p<0.03). Four of 13 individuals with major depressive episodes (MDE) in a cross-sectional study of 50 outpatients at a rehabilitation clinic also had anxiety disorder, as assessed by clinical interview. One cross-sectional study130 intended as a validation study of the HADS to assess depression and anxiety in TBI. Among 34 percent of participants with a SCID-diagnosed depression, about one-third (36 percent) also had a concurrent anxiety disorder.130

All of the available studies reported a high rate of concomitant psychiatric conditions associated with depression after a TBI. Rates ranged from 8 percent to 93 percent depending on the particular psychiatric condition and the study population and design. Those studies that presented data on psychiatric conditions by depression status found higher rates among the depressed groups. None of the studies was able to ascertain directionality for the observed association. Anxiety disorders including generalized anxiety disorder, PTSD, panic disorder, obsessive-compulsive disorder, and specific phobias were the most commonly reported conditions. Most studies grouped these conditions together and reported the overall prevalence of any anxiety disorder.

When the conditions were reported individually, anxiety disorders were most prevalent and affected from 31 percent to 61 percent of study participants in four papers.14,72,109,138 PTSD was observed in 37 percent of depressed patients and none of those without depression.123 Panic disorder was seen in 15 percent of patients with MDE but not measured in those without depression.109

### KQ4 Outcomes of Interventions for Treatment for Depression After TBI

To understand the treatment options for patients with TBI and subsequent depression, we sought publications that clearly documented the intervention, duration, and response to treatment.

#### Treatment Outcomes in TBI

Using this approach, we identified two publications141–142 from two distinct study populations that specifically addressed a treatment intervention for individuals diagnosed with depression after a TBI. Detailed summaries for both studies are included in Appendix C.

One of the treatment studies was conducted in the United States,141 and the second was in Canada.142 Both were studies of medication, the first being a randomized controlled trial (RCT) of sertraline, while the second was an open-label case series of the effects of citalopram.

The study on sertraline was a double-blind placebo controlled trial, with block randomization, in which treatment was administered for 10 weeks.141 Participants were at least 6 months post-TBI, and TBI included documented loss of consciousness or other evidence, such as pathology or imaging. Diagnosis of depression was established with DSM-IV criteria and a Hamilton Rating Scale for Depression (HAM-D) score higher than 18. Dosage of sertraline was not fixed and could be adjusted at 2-week intervals, with a maximum dosage of 200 mg/d. Of 91 individuals screened, 52 were eligible and agreed to participate; 41 completed the study and contributed data to the analysis. Eight of the 11 participants who discontinued were excluded because of noncompliance with the treatment protocol. Generally speaking, participants in this study were middle aged, male, and of lower socioeconomic status (predominantly ≤ $20,000 annually). Time since injury ranged up to 30 years, and reasons for the TBI included assault (46.3 percent), fall (14.6 percent), gunshot wounds (2.4 percent) being hit by a falling object (2.4 percent), and motor vehicle accidents or a pedestrian hit by a moving vehicle (34.2 percent). The primary outcome of interest was a change in depression status measured with the HAM-D. A positive response was considered to be a decrease of 50 percent or a drop below 10 on the HAM-D. Of those who completed the study, 59 percent of the treated group and 32 percent of the control group had a positive response; the difference in response rates between the two groups was not statistically significant (p = 0.08).

Rapoport and colleagues142 studied the effect of citalopram on depressive symptoms after TBI, using an open-label, single arm (case series) design. The study was limited to individuals with mild to moderate TBI. Mild TBI was defined as loss of consciousness at time of injury of 20 minutes or less, an initial GCS of 13–15 and post-traumatic amnesia (PTA) of less than 24 hours. Moderate to severe TBI had a GCS of less than 13, a PTA greater than 24 hours or an abnormal CT image. Fifty-four of 65 patients attending the mild-to-moderate TBI clinic were diagnosed with major depression due to TBI, with a major depressivelike episode, using the depression module of the SCID Axis I disorders. All 65 patients began the study; however, 54 completers provided data for analysis. Although the study was intended to evaluate the effects of a 6-week course of treatment, low response rates resulted in a study extension for some participants to 10 weeks. Therefore, although 6-week data were available for all 54 completers, 10-week data were available for 26 participants. Dosage of citalopram was titrated as deemed medically appropriate by the study physicians. The primary outcome measured was a change on the HAM-D score, with an improvement of 50 percent or more designated a positive response, and a score of less than 8 defined as remission. In the 6-week data (n = 54), 27.7 percent were classified as responders and 24.1 percent were in remission. Among participants with data at 10 weeks, 46.2 percent were responders and 26.9 percent were in remission. Results at both time points were significant (p < .0001). Of the 11 individuals who dropped out of the study, 6 were in the intended 6-week group and 5 were in the intended 10-week group. Ten of the 11 experienced an adverse event.

### KQ5 Comparisons of Treatments

No studies addressed KQ5. It is discussed as a part of Future Research.

### KQ6 Modifiers of Outcomes of Treatment

No studies addressed KQ6. It is discussed as a part of Future Research.

## Grey Literature Results

### Publications Included in This Review

A relevant pool of 56 potentially useful items were located following a series of Internet and relevant grey literature searches of United States government and military sources, nonprofit organizations, United States and international clinical trials registries, meeting proceedings, and dissertation databases. Selected resources were identified from the United States (one government report, one nonprofit white paper, five clinical trial protocols, one funding/grant opportunity, one systematic review, six funded projects, eight conference proceedings, and nine dissertations), New Zealand (one guideline), Australia (two clinical trials), Europe (five conference proceedings, including one from Turkey), and Canada (three clinical trials, one conference proceeding, and one dissertation).

Internet searches. The relevant retrieval from different Google searches included one guideline, two reports, and one systematic review that in whole or in part focus on treatment or screening for depression associated with TBI. A guideline from the New Zealand Guidelines group, not indexed in MEDLINE, provided guidance on treatment of depression in TBI that was based solely on expert opinion, thus contributing little to the literature for this topic. The RAND Corporation and Institute of Medicine (IOM) reports give a review of the current prevalence of depression, PTSD, and TBI in military populations. Only the IOM report provided a review of the literature regarding prevalence or the relationship between TBI and depression, while the RAND report provides a comprehensive overview of the literature for TBI, PTSD, and depression independently. These reports do provide a foundation for future research in the treatment of depression in the context of TBI, but add very little to the published literature summarized in this review.

A systematic review that had not been picked up in the original search of the TBI published literature provided a critical review of literature regarding pharmacologic, other biologic, psychotherapeutic, or rehabilitation treatment of depression after TBI. After a review of 658 articles retrieved from various bibliographic databases, 27 (13 pharmacological, six other biological, and eight psychotherapeutic/rehabilitation intervention) articles were included in the review based on study inclusion/exclusion criteria and study abstract and full-text reviews. The study found a paucity of adequately powered and controlled studies in the literature to make conclusions on the best treatment modality for depression in TBI.

Funding opportunities and ongoing research. Nonpublished grey literature resources may indicate areas of future research for management of depression in TBI patients. Examples include a recent announcement regarding a military funding opportunity to support research in the treatment or prevention of depression or other mood disorders in TBI.143 Also, 6 funded projects from the National Institutes of Health Research Portfolio Online Reporting Tools (RePORTER) and 10 clinical trials from various clinical trials registries report studies underway for treatment of depression in TBI patients. These projects will assess the impact of behavioral therapies;144–152 supportive psychotherapy;153 exercise;154 transcranial magnetic stimulation;155 and drug interventions (e.g. sertraline, venlafaxine, and citalopram).156–158 Several projects also focus on identification of risk factors for depression in the context of TBI.159

Meeting abstracts, proceedings, and dissertations. A significant pool of meeting abstracts, proceedings, and dissertations were retrieved from the literature that focused on topics already covered in the published research. Overall, 14 conference proceedings and 10 dissertations were located that assessed treatment options for depression160–163 and potential methods for characterizing or measuring development of depression in TBI.152,164–182 Examples of therapy modalities include use of nontraditional approaches, such as neurologic music therapy160 and written emotional expression technique,162 and medical approaches with methylphenidate and sertraline drug therapy.161 Lack of reported data makes it difficult to identify or assess any impact of these treatments on depression in TBI patients. Additionally, the papers focusing on patient characteristics or modifiers that may affect outcome,164–166,168–170,172–174,176–177,179,181 disease progression,163,167,175,182 or rating scales171,178,180 of depression in TBI patients provide very little data to make accurate assumptions of reported conclusions.

Summary and literature method critique. A review of the grey literature, government/nonprofit reports, and other unpublished resources did not retrieve much additional information to what had been found in the published and peer-reviewed literature. The majority of the high quality, relevant data comes from two large-scale reports/white papers that mainly focus on the prevalence or the connection between depression and TBI. As was discovered from a review of published literature,183 we noted very little data in the grey literature that assessed the impact of treatment for depression in TBI, although the pool of current clinical trial protocols and funded projects indicate growth in this area of the literature.

During the review of this material, we found some overlap between what was found in the published literature and the current search retrieval. Although we attempted to extract only unique or new data from the pool of grey literature sources, there may be some redundancy in this section of the report given the nature of how this material is reported and maintained in data repositories and online databases.

Citations for all grey literature identified are in Appendix F.