# References and Included Studies

1 Okie S. Traumatic brain injury in the war zone. N Engl J Med. 05. 19. 2005;352(20):2043-2047. [pmid: 15901856].
2 Defense and Veterans Brain Injury Center Working Group on the Acute Management of Mild Traumatic Brain Injury in Military Operational Settings. Clinical Practice Guideline and Recommendations. Washington, D.C. Defense and Veterans Brain Injury Center. 2006.
3 Rutland-Brown W, Langlois JA, Thomas KE, et al. Incidence of traumatic brain injury in the United States, 2003. J Head Trauma Rehabil. 11–12. 2006;21(6):544-548. [pmid: 17122685].
4 Crooks CY, Zumsteg JM, Bell KR. Traumatic brain injury: a review of practice management and recent advances. Phys Med Rehabil Clin N Am. 11. 2007;18(4):681-710. vi. [pmid: 17967360].
5 National Center for Injury Prevention and Control. Report to Congress on Mild Traumatic Brain Injury in the United States: Steps to Prevent a Serious Public Health Problem. Atlanta, GA. Centers for Disease Control and Prevention. 2003.
6 Ivins BJ, Schwab KA, Warden D, et al. Traumatic brain injury in U.S. Army paratroopers: prevalence and character. J Trauma. 10. 2003;55(4):617-621. [pmid: 14566111].
7 Department of Defense Deployment Health Clinical Center. Emerging Health Concerns: Traumatic Brain Injury. Washington, DC. Department of Defense. 2008. Available at: www.pdhealth.mil/TBI.asp#cg.
8 Warden D. Military TBI during the Iraq and Afghanistan wars. J Head Trauma Rehabil. 09–10. 2006;21(5):398-402. [pmid: 16983225].
9 Langlois JA, Rutland-Brown W, Wald MM. The epidemiology and impact of traumatic brain injury: a brief overview. J Head Trauma Rehabil. 09–10. 2006;21(5):375-378. [pmid: 16983222].
10 Rehabilitation of persons with traumatic brain injury. NIH Consens Statement. 10. 26–28. 1998;16(1):1-41.
11 Kim E, Lauterbach EC, Reeve A, et al. Neuropsychiatric complications of traumatic brain injury: a critical review of the literature (a report by the ANPA Committee on Research). J Neuropsychiatry Clin Neurosci. Spring. 2007;19(2):106-127. [pmid: 17431056].
12 O’Donnell ML, Creamer M, Pattison P, et al. Psychiatric morbidity following injury. Am J Psychiatry. 03. 2004;161(3):507-514. [pmid: 14992977].
13 Varney NR, Martzke JS, Roberts RJ. Major depression in patients with closed head injury. Neuropsychology. 05. 1987;1(1):7-9.
14 Jorge RE, Robinson RG, Starkstein SE, et al. Depression and anxiety following traumatic brain injury. J Neuropsychiatry Clin Neurosci. Fall. 1993;5(4):369-374. [pmid: 8286933].
15 Holsinger T, Steffens DC, Phillips C, et al. Head injury in early adulthood and the lifetime risk of depression. Arch Gen Psychiatry. 01. 2002;59(1):17-22. [pmid: 11779276].
16 Gordon WA, Zafonte R, Cicerone K, et al. Traumatic brain injury rehabilitation: state of the science. Am J Phys Med Rehabil. 04. 2006;85(4):343-382. [pmid: 16554685].
17 Busch CR, Alpern HP. Depression after mild traumatic brain injury: a review of current research. Neuropsychol Rev. 06. 1998;8(2):95-108. [pmid: 9658412].
18 Graham DI, Lantos PL, editors. Greenfield’s Neuropathology. 7. London. Arnold. 2002.
19 Wilk JE, Thomas JL, McGurk DM, et al. Mild traumatic brain injury (concussion) during combat: lack of association of blast mechanism with persistent postconcussive symptoms. J Head Trauma Rehabil. 01–02. 2010;25(1):9-14. [pmid: 20051900].
20 Babin PR. Diagnosing depression in persons with brain injuries: A look at theories, the DSM-IV and depression measures. Brain Injury. 10. 2003;17(10):889-900. [pmid: 12963555].
21 Alderfer BS, Arciniegas DB, Silver JM. Treatment of depression following traumatic brain injury. Journal of Head Trauma Rehabilitation. 11–12. 2005;20(6):544-562. [pmid: 16304490].
22 Trivedi MH, Kleiber BA. Algorithm for the treatment of chronic depression. J Clin Psychiatry. 2001;62(Suppl 6):22-29. [pmid: 11310816].
23 Ereshefsky L. The Texas Medication Algorithm Project for major depression. Manag Care. 08. 2001;10(8 Suppl):16-7. discussion 18–22. [pmid: 11729434].
24 Moher D, Pham, Klassen TP, et al. What contributions do languages other than English make on the results of meta-analyses?. Journal of Clinical Epidemiology. [doi: 10.1016/S0895-4356(00)00188-8]. 2000;53(9):964-972. [pmid: 11004423].
25 Berney J, Favier J, Froidevaux AC. Paediatric head trauma: influence of age and sex. I. Epidemiology. Childs Nerv Syst. 11. 1994;10(8):509-516. [pmid: 7882373].
26 Matchar DB, Myers ER, Barber MW, et al. Management of uterine fibroids. Evid Rep Technol Assess (Summ). 01. 2001;34:1-6. [pmid: 11236283].
27 Schulz KF, Chalmers I, Grimes DA, et al. Assessing the quality of randomization from reports of controlled trials published in obstetrics and gynecology journals. JAMA. 07. 13. 1994;272(2):125-128. [pmid: 8015122].
28 Schulz KF, Chalmers I, Hayes RJ, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 02. 1. 1995;273(5):408-412. [pmid: 7823387].
29 Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions-Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. 2009. 07. 10.
30 Hoge CW, McGurk D, Thomas JL, et al. Mild traumatic brain injury in U.S. Soldiers returning from Iraq. N Engl J Med. 01. 31. 2008;358(5):453-463. [pmid: 18234750].
31 Hoofien D, Gilboa A, Vakil E, et al. Traumatic brain injury (TBI) 10–20 years later: a comprehensive outcome study of psychiatric symptomatology, cognitive abilities and psychosocial functioning. Brain Inj. 03. 2001;15(3):189-209. [pmid: 11260769].
32 Whelan-Goodinson R, Ponsford J, Schonberger M. Association between psychiatric state and outcome following traumatic brain injury. J Rehabil Med. 11. 2008;40(10):850-857. [pmid: 19242623].
33 Hawley CA, Joseph S. Predictors of positive growth after traumatic brain injury: a longitudinal study. Brain Inj. 05. 2008;22(5):427-435. [pmid: 18415723].
34 Rao V, Spiro J, Vaishnavi S, et al. Prevalence and types of sleep disturbances acutely after traumatic brain injury. Brain Inj. 05. 2008;22(5):381-386. [pmid: 18415718].
35 Lima DP, Simao Filho C, Abib Sde C, et al. Quality of life and neuropsychological changes in mild head trauma. Late analysis and correlation with S100B protein and cranial CT scan performed at hospital admission. Injury. 05. 2008;39(5):604-611. [pmid: 18329647].
36 Bay E, Donders J. Risk factors for depressive symptoms after mild-to-moderate traumatic brain injury. Brain Inj. 03. 2008;22(3):233-241. [pmid: 18297595].
37 Ruocco AC, Swirsky-Sacchetti T, Choca JP. Assessing personality and psychopathology after traumatic brain injury with the Millon Clinical Multiaxial Inventory-III. Brain Inj. 11. 2007;21(12):1233-1244. [pmid: 18236199].
38 Stalnacke BM. Community integration, social support and life satisfaction in relation to symptoms 3 years after mild traumatic brain injury. Brain Inj. 08. 2007;21(9):933-942. [pmid: 17729046].
39 Keiski MA, Shore DL, Hamilton JM. The role of depression in verbal memory following traumatic brain injury. Clin Neuropsychol. 09. 2007;21(5):744-761. [pmid: 17676541].
40 Sherer M, Evans CC, Leverenz J, et al. Therapeutic alliance in post-acute brain injury rehabilitation: predictors of strength of alliance and impact of alliance on outcome. Brain Inj. 06. 2007;21(7):663-672. [pmid: 17653940].
41 Al-Adawi S, Dorvlo AS, Al-Naamani A, et al. The ineffectiveness of the Hospital Anxiety and Depression Scale for diagnosis in an Omani traumatic brain injured population. Brain Inj. 04. 2007;21(4):385-393. [pmid: 17487636].
42 Deb S, Burns J. Neuropsychiatric consequences of traumatic brain injury: a comparison between two age groups. Brain Inj. 03. 2007;21(3):301-307. [pmid: 17453758].
43 Schofield PW, Butler TG, Hollis SJ, et al. Neuropsychiatric correlates of traumatic brain injury (TBI) among Australian prison entrants. Brain Inj. 12. 2006;20(13–14):1409-1418. [pmid: 17378233].
44 Bay E, Hagerty BM, Williams RA. Depressive symptomatology after mild-to-moderate traumatic brain injury: a comparison of three measures. Arch Psychiatr Nurs. 02. 2007;21(1):2-11. [pmid: 17258103].
45 Marsh NV, Kersel DA. Frequency of behavioural problems at one year following traumatic brain injury: correspondence between patient and caregiver reports. Neuropsychol Rehabil. 12. 2006;16(6):684-694. [pmid: 17127573].
46 Chiu WT, Huang SJ, Hwang HF, et al. Use of the WHOQOL-BREF for evaluating persons with traumatic brain injury. J Neurotrauma. 11. 2006;23(11):1609-1620. [pmid: 17115908].
47 Ghaffar O, McCullagh S, Ouchterlony D, et al. Randomized treatment trial in mild traumatic brain injury. J Psychosom Res. 08. 2006;61(2):153-160. [pmid: 16880017].
48 Frenisy MC, Benony H, Chahraoui K, et al. Brain injured patients versus multiple trauma patients: some neurobehavioral and psychopathological aspects. J Trauma. 05. 2006;60(5):1018-1026. [pmid: 16688064].
49 Rapoport MJ, Herrmann N, Shammi P, et al. Outcome after traumatic brain injury sustained in older adulthood: a one-year longitudinal study. Am J Geriatr Psychiatry. 05. 2006;14(5):456-465. [pmid: 16670250].
50 Chamelian L, Feinstein A. The effect of major depression on subjective and objective cognitive deficits in mild to moderate traumatic brain injury. J Neuropsychiatry Clin Neurosci. Winter. 2006;18(1):33-38. [pmid: 16525068].
51 Koponen S, Taiminen T, Kurki T, et al. MRI findings and Axis I and II psychiatric disorders after traumatic brain injury: a 30-year retrospective follow-up study. Psychiatry Res. 04. 30. 2006;146(3):263-270. [pmid: 16507345].
52 Rapoport MJ, Kiss A, Feinstein A. The impact of major depression on outcome following mild-to-moderate traumatic brain injury in older adults. J Affect Disord. 06. 2006;92(2–3):273-276. [pmid: 16504305].
53 Parcell DL, Ponsford JL, Rajaratnam SM, et al. Self-reported changes to nighttime sleep after traumatic brain injury. Arch Phys Med Rehabil. 02. 2006;87(2):278-285. [pmid: 16442985].
54 Kashluba S, Casey JE, Paniak C. Evaluating the utility of ICD-10 diagnostic criteria for postconcussion syndrome following mild traumatic brain injury. J Int Neuropsychol Soc. 01. 2006;12(1):111-118. [pmid: 16433950].
55 Gagnon J, Bouchard MA, Rainville C, et al. Inhibition and object relations in borderline personality traits after traumatic brain injury. Brain Inj. 01. 2006;20(1):67-81. [pmid: 16403702].
56 Felde AB, Westermeyer J, Thuras P. Co-morbid traumatic brain injury and substance use disorder: childhood predictors and adult correlates. Brain Inj. 01. 2006;20(1):41-49. [pmid: 16403699].
57 Kennedy RE, Livingston L, Riddick A, et al. Evaluation of the Neurobehavioral Functioning Inventory as a depression screening tool after traumatic brain injury. J Head Trauma Rehabil. 11–12. 2005;20(6):512-526. [pmid: 16304488].
58 Evans CC, Sherer M, Nick TG, et al. Early impaired self-awareness, depression, and subjective well-being following traumatic brain injury. J Head Trauma Rehabil. 11–12. 2005;20(6):488-500. [pmid: 16304486].
59 Huang DB, Spiga R, Koo H. Use of the Zung depression scale in patients with traumatic brain injury: 1 year post-injury. Brain Inj. 10. 2005;19(11):903-908. [pmid: 16299933].
60 Mooney G, Speed J, Sheppard S. Factors related to recovery after mild traumatic brain injury. Brain Inj. 11. 2005;19(12):975-987. [pmid: 16263640].
61 Koponen S, Taiminen T, Honkalampi K, et al. Alexithymia after traumatic brain injury: its relation to magnetic resonance imaging findings and psychiatric disorders. Psychosom Med. 09–10. 2005;67(5):807-812. [pmid: 16204442].
62 McCauley SR, Boake C, Pedroza C, et al. Postconcussional disorder: Are the DSM-IV criteria an improvement over the ICD-10?. J Nerv Ment Dis. 08. 2005;193(8):540-550. [pmid: 16082299].
63 Levin HS, McCauley SR, Josic CP, et al. Predicting depression following mild traumatic brain injury. Arch Gen Psychiatry. 05. 2005;62(5):523-528. [pmid: 15867105].
64 Rowland SM, Lam CS, Leahy B. Use of the Beck Depression Inventory-II (BDI-II) with persons with traumatic brain injury: analysis of factorial structure. Brain Inj. 02. 2005;19(2):77-83. [pmid: 15841751].
65 Popovic V, Pekic S, Pavlovic D, et al. Hypopituitarism as a consequence of traumatic brain injury (TBI) and its possible relation with cognitive disabilities and mental distress. J Endocrinol Invest. 12. 2004;27(11):1048-1054. [pmid: 15754737].
66 Rapoport MJ, McCullagh S, Shammi P, et al. Cognitive impairment associated with major depression following mild and moderate traumatic brain injury. J Neuropsychiatry Clin Neurosci. Winter. 2005;17(1):61-65. [pmid: 15746484].
67 Chamelian L, Reis M, Feinstein A. Six-month recovery from mild to moderate Traumatic Brain Injury: the role of APOE-epsilon4 allele. Brain. 12. 2004;127(Pt 12):2621-2628. [pmid: 15496436].
68 Brown SA, McCauley SR, Levin HS, et al. Perception of health and quality of life in minorities after mild-to-moderate traumatic brain injury. Appl Neuropsychol. 2004;11(1):54-64. [pmid: 15471747].
69 Koponen S, Taiminen T, Kairisto V, et al. APOE-epsilon4 predicts dementia but not other psychiatric disorders after traumatic brain injury. Neurology. 08. 24. 2004;63(4):749-750. [pmid: 15326261].
70 Hibbard MR, Ashman TA, Spielman LA, et al. Relationship between depression and psychosocial functioning after traumatic brain injury. Arch Phys Med Rehabil. 04. 2004;85(4 Suppl 2):S43-53. [pmid: 15083421].
71 Ashman TA, Spielman LA, Hibbard MR, et al. Psychiatric challenges in the first 6 years after traumatic brain injury: cross-sequential analyses of Axis I disorders. Arch Phys Med Rehabil. 04. 2004;85(4 Suppl 2):S36-42. [pmid: 15083420].
72 Jorge RE, Robinson RG, Moser D, et al. Major depression following traumatic brain injury. Arch Gen Psychiatry. 01. 2004;61(1):42-50. [pmid: 14706943].
73 Franulic A, Carbonell CG, Pinto P, et al. Psychosocial adjustment and employment outcome 2, 5 and 10 years after TBI. Brain Inj. 02. 2004;18(2):119-129. [pmid: 14660225].
74 Seel RT, Kreutzer JS. Depression assessment after traumatic brain injury: an empirically based classification method. Arch Phys Med Rehabil. 11. 2003;84(11):1621-1628. [pmid: 14639561].
75 Slaughter B, Fann JR, Ehde D. Traumatic brain injury in a county jail population: prevalence, neuropsychological functioning and psychiatric disorders. Brain Inj. 09. 2003;17(9):731-741. [pmid: 12850940].
76 Tateno A, Jorge RE, Robinson RG. Clinical correlates of aggressive behavior after traumatic brain injury. J Neuropsychiatry Clin Neurosci. Spring. 2003;15(2):155-160. [pmid: 12724455].
77 Rapoport MJ, McCullagh S, Streiner D, et al. Age and major depression after mild traumatic brain injury. Am J Geriatr Psychiatry. 05–06. 2003;11(3):365-369. [pmid: 12724117].
78 Seel RT, Kreutzer JS, Rosenthal M, et al. Depression after traumatic brain injury: a National Institute on Disability and Rehabilitation Research Model Systems multicenter investigation. Arch Phys Med Rehabil. 02. 2003;84(2):177-184. [pmid: 12601647].
79 Rapoport MJ, McCullagh S, Streiner D, et al. The clinical significance of major depression following mild traumatic brain injury. Psychosomatics. 01–02. 2003;44(1):31-37. [pmid: 12515835].
80 Bay E, Hagerty BM, Williams RA, et al. Chronic stress, sense of belonging, and depression among survivors of traumatic brain injury. J Nurs Scholarsh. 2002;34(3):221-226. [pmid: 12237983].
81 Koponen S, Taiminen T, Portin R, et al. Axis I and II psychiatric disorders after traumatic brain injury: a 30-year follow-up study. Am J Psychiatry. 08. 2002;159(8):1315-1321. [pmid: 12153823].
82 Rapoport M, McCauley S, Levin H, et al. The role of injury severity in neurobehavioral outcome 3 months after traumatic brain injury. Neuropsychiatry Neuropsychol Behav Neurol. 06. 2002;15(2):123-132. [pmid: 12050475].
83 McCauley SR, Boake C, Levin HS, et al. Postconcussional disorder following mild to moderate traumatic brain injury: anxiety, depression, and social support as risk factors and comorbidities. J Clin Exp Neuropsychol. 12. 2001;23(6):792-808. [pmid: 11910545].
84 Levin HS, Brown SA, Song JX, et al. Depression and posttraumatic stress disorder at three months after mild to moderate traumatic brain injury. J Clin Exp Neuropsychol. 12. 2001;23(6):754-769. [pmid: 11910542].
85 Powell J, Heslin J, Greenwood R. Community based rehabilitation after severe traumatic brain injury: a randomised controlled trial. J Neurol Neurosurg Psychiatry. 02. 2002;72(2):193-202. [pmid: 11796769].
86 McCauley SR, Levin HS, Vanier M, et al. The neurobehavioural rating scale-revised: sensitivity and validity in closed head injury assessment. J Neurol Neurosurg Psychiatry. 11. 2001;71(5):643-651. [pmid: 11606677].
87 Mooney G, Speed J. The association between mild traumatic brain injury and psychiatric conditions. Brain Inj. 10. 2001;15(10):865-877. [pmid: 11595083].
88 Kersel DA, Marsh NV, Havill JH, et al. Psychosocial functioning during the year following severe traumatic brain injury. Brain Inj. 08. 2001;15(8):683-696. [pmid: 11485609].
89 Kreutzer JS, Seel RT, Gourley E. The prevalence and symptom rates of depression after traumatic brain injury: a comprehensive examination. Brain Inj. 07. 2001;15(7):563-576. [pmid: 11429086].
90 Bryant RA, Marosszeky JE, Crooks J, et al. Posttraumatic stress disorder and psychosocial functioning after severe traumatic brain injury. J Nerv Ment Dis. 02. 2001;189(2):109-113. [pmid: 11225683].
91 Curran CA, Ponsford JL, Crowe S. Coping strategies and emotional outcome following traumatic brain injury: a comparison with orthopedic patients. J Head Trauma Rehabil. 12. 2000;15(6):1256-1274. [pmid: 11056407].
92 Vasterling JJ, Constans JI, Hanna-Pladdy B. Head injury as a predictor of psychological outcome in combat veterans. J Trauma Stress. 07. 2000;13(3):441-451. [pmid: 10948484].
93 Sherman EM, Strauss E, Slick DJ, et al. Effect of depression on neuropsychological functioning in head injury: measurable but minimal. Brain Inj. 07. 2000;14(7):621-632. [pmid: 10914644].
94 Perlesz A, Kinsella G, Crowe S. Psychological distress and family satisfaction following traumatic brain injury: injured individuals and their primary, secondary, and tertiary carers. J Head Trauma Rehabil. 06. 2000;15(3):909-929. [pmid: 10785622].
95 Deb S, Lyons I, Koutzoukis C. Neurobehavioural symptoms one year after a head injury. Br J Psychiatry. 04. 1999;174:360-365. [pmid: 10533556].
96 Deb S, Lyons I, Koutzoukis C, et al. Rate of psychiatric illness 1 year after traumatic brain injury. Am J Psychiatry. 03. 1999;156(3):374-378. [pmid: 10080551].
97 Gordon WA, Brown M, Sliwinski M, et al. The enigma of “hidden” traumatic brain injury. J Head Trauma Rehabil. 12. 1998;13(6):39-56. [pmid: 9885317].
98 Sebit MB, Siziya S, Ndetei DM, et al. Study of psychiatric consequences of closed head injury at the Kenyatta National Hospital. East Afr Med J. 06. 1998;75(6):332-335. [pmid: 9803614].
99 McCleary C, Satz P, Forney D, et al. Depression after traumatic brain injury as a function of Glasgow Outcome Score. J Clin Exp Neuropsychol. 04. 1998;20(2):270-279. [pmid: 9777481].
100 Satz P, Zaucha K, Forney DL, et al. Neuropsychological, psychosocial and vocational correlates of the Glasgow Outcome Scale at 6 months post-injury: a study of moderate to severe traumatic brain injury patients. Brain Inj. 07. 1998;12(7):555-567. [pmid: 9653519].
101 Satz P, Forney DL, Zaucha K, et al. Depression, cognition, and functional correlates of recovery outcome after traumatic brain injury. Brain Inj. 07. 1998;12(7):537-553. [pmid: 9653518].
102 Gordon WA, Sliwinski M, Echo J, et al. The benefits of exercise in individuals with traumatic brain injury: a retrospective study. J Head Trauma Rehabil. 08. 1998;13(4):58-67. [pmid: 9651240].
103 Sliwinski M, Gordon WA, Bogdany J. The Beck Depression Inventory: is it a suitable measure of depression for individuals with traumatic brain injury?. J Head Trauma Rehabil. 08. 1998;13(4):40-46. [pmid: 9651238].
104 Hibbard MR, Uysal S, Kepler K, et al. Axis I psychopathology in individuals with traumatic brain injury. J Head Trauma Rehabil. 08. 1998;13(4):24-39. [pmid: 9651237].
105 Kreuter M, Dahllof AG, Gudjonsson G, et al. Sexual adjustment and its predictors after traumatic brain injury. Brain Inj. 05. 1998;12(5):349-368. [pmid: 9591141].
106 Kreuter M, Sullivan M, Dahllof AG, et al. Partner relationships, functioning, mood and global quality of life in persons with spinal cord injury and traumatic brain injury. Spinal Cord. 04. 1998;36(4):252-261. [pmid: 9589525].
107 Kant R, Duffy JD, Pivovarnik A. Prevalence of apathy following head injury. Brain Inj. 01. 1998;12(1):87-92. [pmid: 9483342].
108 Gomez-Hernandez R, Max JE, Kosier T, et al. Social impairment and depression after traumatic brain injury. Arch Phys Med Rehabil. 12. 1997;78(12):1321-1326. [pmid: 9421985].
109 Fann JR, Katon WJ, Uomoto JM, et al. Psychiatric disorders and functional disability in outpatients with traumatic brain injuries. Am J Psychiatry. 10. 1995;152(10):1493-1499. [pmid: 7573589].
110 Aloia MS, Long CJ, Allen JB. Depression among the head-injured and non-head-injured: a discriminant analysis. Brain Inj. 08–09. 1995;9(6):575-583. [pmid: 7581353].
111 Jorge RE, Robinson RG, Starkstein SE, et al. Influence of major depression on 1-year outcome in patients with traumatic brain injury. J Neurosurg. 11. 1994;81(5):726-733. [pmid: 7931619].
112 Linn RT, Allen K, Willer BS. Affective symptoms in the chronic stage of traumatic brain injury: a study of married couples. Brain Inj. 02–03. 1994;8(2):135-147. [pmid: 8193633].
113 MacNiven E, Finlayson MA. The interplay between emotional and cognitive recovery after closed head injury. Brain Inj. 05–06. 1993;7(3):241-246. [pmid: 8508180].
114 Jorge RE, Robinson RG, Arndt SV, et al. Depression following traumatic brain injury: a 1 year longitudinal study. J Affect Disord. 04. 1993;27(4):233-243. [pmid: 8509524].
115 Jorge RE, Robinson RG, Arndt S. Are there symptoms that are specific for depressed mood in patients with traumatic brain injury?. J Nerv Ment Dis. 02. 1993;181(2):91-99. [pmid: 8426177].
116 Jorge RE, Robinson RG, Arndt SV, et al. Comparison between acute- and delayed-onset depression following traumatic brain injury. J Neuropsychiatry Clin Neurosci. Winter. 1993;5(1):43-49. [pmid: 8428134].
117 Fedoroff JP, Starkstein SE, Forrester AW, et al. Depression in patients with acute traumatic brain injury. Am J Psychiatry. 07. 1992;149(7):918-923. [pmid: 1609872].
118 Gass CS, Russell EW. MMPI profiles of closed head trauma patients: impact of neurologic complaints. J Clin Psychol. 03. 1991;47(2):253-260. [pmid: 2030130].
119 Dunlop TW, Udvarhelyi GB, Stedem AF, et al. Comparison of patients with and without emotional/behavioral deterioration during the first year after traumatic brain injury. J Neuropsychiatry Clin Neurosci. Spring. 1991;3(2):150-156. [pmid: 1821228].
120 Mobayed M, Dinan TG. Buspirone/prolactin response in post head injury depression. J Affect Disord. 08. 1990;19(4):237-241. [pmid: 2146299].
121 Kinsella G, Moran C, Ford B, et al. Emotional disorder and its assessment within the severe head injured population. Psychol Med. 02. 1988;18(1):57-63. [pmid: 2966415].
122 Brooks N, Campsie L, Symington C, et al. The effects of severe head injury on patient and relative within seven years of injury. Journal of Head Trauma Rehabilitation. 1987;2(3):1-13.
123 Bombardier CH, Fann JR, Temkin N, et al. Posttraumatic stress disorder symptoms during the first six months after traumatic brain injury. J Neuropsychiatry Clin Neurosci. Fall. 2006;18(4):501-508. [pmid: 17135375].
124 Wade DT, King NS, Wenden FJ, et al. Routine follow up after head injury: a second randomised controlled trial. J Neurol Neurosurg Psychiatry. 08. 1998;65(2):177-183. [pmid: 9703167].
125 Ziino C, Ponsford J. Selective attention deficits and subjective fatigue following traumatic brain injury. Neuropsychology. 05. 2006;20(3):383-390. [pmid: 16719631].
126 Tateno A, Jorge RE, Robinson RG. Pathological laughing and crying following traumatic brain injury. J Neuropsychiatry Clin Neurosci. Fall. 2004;16(4):426-434. [pmid: 15616168].
127 Fann JR, Jones AL, Dikmen SS, et al. Depression treatment preferences after traumatic brain injury. J Head Trauma Rehabil. 07–08. 2009;24(4):272-278. [pmid: 19625866].
128 Homaifar BY, Brenner LA, Gutierrez PM, et al. Sensitivity and specificity of the Beck Depression Inventory-II in persons with traumatic brain injury. Arch Phys Med Rehabil. 04. 2009;90(4):652-656. [pmid: 19345782].
129 Himanen L, Portin R, Tenovuo O, et al. Attention and depressive symptoms in chronic phase after traumatic brain injury. Brain Inj. 03. 2009;23(3):220-227. [pmid: 19205958].
130 Whelan-Goodinson R, Ponsford J, Schonberger M. Validity of the Hospital Anxiety and Depression Scale to assess depression and anxiety following traumatic brain injury as compared with the Structured Clinical Interview for DSM-IV. J Affect Disord. 04. 2009;114(1–3):94-102. [pmid: 18656266].
131 Mollica RF, Lyoo IK, Chernoff MC, et al. Brain structural abnormalities and mental health sequelae in South Vietnamese expolitical detainees who survived traumatic head injury and torture. Arch Gen Psychiatry. 11. 2009;66(11):1221-1232. [pmid: 19884610].
132 Peleg G, Barak O, Harel Y, et al. Hope, dispositional optimism and severity of depression following traumatic brain injury. Brain Injury. 09. 2009;23(10):800-808. [pmid: 19697168].
133 Hawthorne G, Gruen RL, Kaye AH. Traumatic brain injury and long-term quality of life: findings from an Australian study. J Neurotrauma. 10. 2009;26(10):1623-1633. [pmid: 19317590].
134 Bryant RA, O’Donnell ML, Creamer M, et al. The psychiatric sequelae of traumatic injury. Am J Psychiatry. 03. 2010;167(3):312-320. [pmid: 20048022].
135 Herrmann N, Rapoport MJ, Rajaram RD, et al. Factor analysis of the Rivermead Post-Concussion Symptoms Questionnaire in mild-to-moderate traumatic brain injury patients. J Neuropsychiatry Clin Neurosci. Spring. 2009;21(2):181-188. [pmid: 19622689].
136 Rao V, Rosenberg P, Bertrand M, et al. Aggression after traumatic brain injury: prevalence and correlates. J Neuropsychiatry Clin Neurosci. Fall. 2009;21(4):420-429. [pmid: 19996251].
137 Ponsford J, Schönberger M. Family functioning and emotional state two and five years after traumatic brain injury. Journal of the International Neuropsychological Society. 03. 2010;16(2):306-317. [pmid: 20128950].
138 Bombardier CH, Fann JR, Temkin NR, et al. Rates of Major Depressive Disorder and Clinical Outcomes Following Traumatic Brain Injury. JAMA. 05. 19. 2010;303(19):1938-1945. [pmid: 20483970].
139 Fann JR, Bombardier CH, Dikmen S, et al. Validity of the Patient Health Questionnaire-9 in assessing depression following traumatic brain injury. J Head Trauma Rehabil. 11–12. 2005;20(6):501-511. [pmid: 16304487].
140 Batten SV, Pollack SJ. Integrative outpatient treatment for returning service members. J Clin Psychol. 08. 2008;64(8):928-939. [pmid: 18561182].
141 Ashman TA, Cantor JB, Gordon WA, et al. A randomized controlled trial of sertraline for the treatment of depression in persons with traumatic brain injury. Arch Phys Med Rehabil. 05. 2009;90(5):733-740. [pmid: 19406291].
142 Rapoport MJ, Chan F, Lanctot K, et al. An open-label study of citalopram for major depression following traumatic brain injury. J Psychopharmacol. 11. 2008;22(8):860-864. [pmid: 18208921].
143 United States Army Medical Research Acquisition Activity. Psychological Health and Traumatic Brain Injury Advanced Technology/Therapeutic Development Award. Available at: www.grants.gov. Accessed February 9, 2010.
144 University of Iowa, National Institute of Neurological Disorders and Stroke. Treatment strategy to prevent mood disorders following traumatic brain injury. Received June 20, 2008. Available at: www.clinicaltrials.gov. Accessed February 8, 2010.
145 University of Washington. Telephone and in-person cognitive behavioral therapy for depression after traumatic brain injury. Start date: October 1, 2007. Available at: http://www.naric.com/research/record.cfm?search=1&type=all&criteria=brain%20injuriesdepression&phrase=no&rec=1751. Accessed February 8, 2010.
146 Memorial Herman The Institute for Rehabilitation and Research. Effectiveness of a Group Cognitive-Behavioral Intervention for Depression after TBI and Factors that Affect Response to Treatment. Start date: October 1, 2007. Available at: http://www.naric.com/research/record.cfm?search=1&type=all&criteria=brain%20injuries%20depression&phrase=no&rec=1772. Accessed February 8, 2010.
147 University of Washington. Phone cognitive behavioral therapy for depression after traumatic brain injury. Available at: http://projectreporter.nih.gov/project_info_description.cfm?projectnumber=1R21HD053736-01A1. Accessed February 8, 2010.
148 University of Illinois at Chicago. Neuropsychiatry of traumatic brain injury. Available at: http://projectreporter.nih.gov/project_info_description.cfm?aid=7383126&icde=7233193. Accessed February 8, 2010.
149 Lakehead University Ontario Neurotrauma Foundation. Mindfulness-Based Cognitive Therapy Intervention to Treat Depression in Individuals with a Traumatic Brain Injury. Received September 2, 2008. Available at: www.clinicaltrials.gov. Accessed February 8, 2010.
150 Toronto Rehabilitation Institute Ontario Neurotrauma Foundation Peel Halton Acquired Brain Injury Services. Improving Psychological Wellness After Acquired Brain Injury. Received March 19, 2009. Available at: www.clinicaltrials.gov. Accessed February 8, 2010.
151 Monash University. The use of Motivational Interviewing and cognitive behavioural therapy to treat anxiety and/or depression following traumatic brain injury. Available at: http://apps.who.int/trialsearch/trial.aspx?trialid=ACTRN12609000456257. Accessed February 8, 2010.
152 Mauri MC, Colasanti A, Paletta S, et al. Post traumatic brain injury major depression and primary major depression: psychopathological and neuropsychological profiles. European Neuropsychopharmacology. 09. 2009;19(Suppl 3):S389.
153 Mount Sinai School of Medicine U.S. Department of Education. Treatment of Post-TBI Depression Conditions. Received September 16, 2005. Available at: www.clinicaltrials.gov. Accessed February 8, 2010.
154 University of Washington. The Effect of Exercise on Mood After Traumatic Brain Injury. Received December 10, 2007. Available at: www.clinicaltrials.gov. Accessed February 8, 2010.
155 Bayside Health. TMS in the Treatment of the Sequelae of Closed Brain Injury. Received September 17, 2007. Available at: www.clinicaltrials.gov. Accessed February 8, 2010.
156 University of Iowa, National Institute of Neurological Disorders and Stroke (NINDS). Treatment Strategy to Prevent Mood Disorders Following Traumatic Brain Injury. Received June 20, 2008. Available at: www.clinicaltrials.gov. Accessed February 8, 2010.
157 Virginia Commonwealth University, U. S. Department of Education. Pharmacological Intervention in Depression After Traumatic Brain Injury. Received September 12, 2005. Available at: www.clinicaltrials.gov. Accessed February 8, 2010.
158 Sunnybrook Health Sciences Centre, Ontario Mental Health Foundation. Depression and Traumatic Brain Injury. Received November 10, 2005. Available at: www.clinicaltrials.gov. Accessed February 8, 2010.
159 Johns Hopkins University. Post traumatic brain injury (TBI) depression. Available at: http://projectreporter.nih.gov/project_info_description.cfm?projectnumber=5K23MH066894-04. Accessed February 8, 2010.
160 Colasanti A, Mauri MC, Paletta S, et al. Primary major depression versus post-traumatic brain injury major depression: psychopathological and neuropsychological differences. European Neuropsychopharmacology. 08. 2008;18(Suppl 4):S582-S583.
161 Buzzi MG, Bivona U, Matteis M, et al. Cognitive and psychological patterns in post-traumatic headache following severe traumatic brain injury. Cephalalgia. 09. 2003;23(7):672.
162 Wegner RC. Spirituality and religion as predictors of mood and quality of life following traumatic brain injury [dissertation]. Boston. Massachusetts School of Professional Psychology. 2008.
163 Statman SH. The evolution of depression over the first two years post head trauma [dissertation]. Philadelphia. Temple University. 1989.
164 Thaut MH, Gardiner JC, Holmberg D, et al. Neurologic Music Therapy Improves Executive Function and Emotional Adjustment in Traumatic Brain Injury Rehabilitation. Dalla Bella S, Kraus N, Overy K, et al., editors. Neurosciences and Music III: Disorders and Plasticity. Hoboken, NJ. Wiley-Blackwell. 2009:406-416.
165 Mauri MC, Colasanti A, Natoli A, et al. Psychiatric and neuropsychological sequelae of TBI: a case-control, longitudinal study. International Journal of Neuropsychopharmacology. 07. 2008;11(Suppl 1):308.
166 Hou J-GG, Lai E. Previous traumatic brain injury may be a risk factor of mood disorders in Parkinson’s disease. Neurology. 03. 11. 2008;70(11 Suppl 1):A438.
167 Lee H, Kim S, Kim J, et al. Comparing effects of methylphenidate, sertraline and placebo on depressive symptoms and psychomotor function in patients with traumatic brain injury. International Journal of Neuropsychopharmacology. 06. 2004;7(Suppl 2):S274.
168 Anderson SS. The effect of written emotional expression on depression following mild traumatic brain injury: A pilot study [dissertation]. Philadelphia. Drexel University. 2008.
169 Shepherd JG Jr. Coping style as mediator of health-related quality of life and depression after an acquired brain injury [dissertation]. Santa Barbara. Fielding Graduate University. 2007.
170 Jordan BD, Glass E, Ortega-Verdejo K. Assessment of neuropsychiatric symptoms in patients with traumatic brain injury. Neurology. 04. 9. 2002;58(7 Supp 3):A357.
171 Van Den Eeden SK, Tanner CM, Popat RA, et al. The risk of Parkinson’s disease associated with head injury and depression: A population-based case-control study. Neurology. 04. 11. 2000;54(7 Supp 3):A347.
172 Holtzer R, Burright RG, Donovick PJ. Depression and brain injury history of psychiatric patients. Society for Neuroscience—Abstracts. 1998;24(1–2):740.
173 Warden DL, Dougherty DS, Quintero-Sheeley E, et al. Psychotic symptoms following moderate traumatic brain injury. Neurology. 1994;44(4 Suppl 2):A401.
174 Rao N. Suicide after successful rehabilitation of traumatic brain injury. Archives of Physical Medicine and Rehabilitation. 1991;72(10):818.
175 Van Mier H, Hulstijn W, Tromp E, et al. Fine motor performance in closed head injury and depression. Society for Neuroscience—Abstracts. 1990;16(2):1317.
176 O’Brien KP. Relationship of psychosocial and physical dysfunction to emotional adjustment after traumatic brain injury. Journal of Clinical and Experimental Neuropsychology. 1988;10(1):41-42.
177 Fenimore EA. Depression following traumatic brain injury and the Hamilton Depression Rating Scale [dissertation]. Palo Alto, CA. Pacific Graduate School of Psychology. 2006.
178 Bay EH. Chronic stress, cortisol regulation, interpersonal relatedness, cognitive burden, and depressive symptoms among community-dwelling survivors of brain injury [unpublished dissertation]. Ann Arbor, MI. University of Michigan. 2001.
179 Sinacori DR. Depression in a brain-injured sample: An investigation of indicators on the Rorschach and MMPI-2 [dissertation]. Chester, PA. Widener University. 1999.
180 Ruttan LA. Depression and neuropsychological functioning in mild traumatic brain injury [dissertation]. Toronto. York University. 1998.
181 Burg JS. Psychiatric treatment outcome following traumatic brain injury [dissertation]. Binghamton. State University of New York at Binghamton. 1997.
182 Mervak TA. Physical and psychological factors in depression following closed head trauma [dissertation]. Boston. Boston University. 1979.
183 Fann JR, Hart T, Schomer KG. Treatment for depression after traumatic brain injury: a systematic review. J Neurotrauma. 12. 2009;26(12):2383-2402. [pmid: 19698070].