# Methods

In this chapter we document the procedures that the Vanderbilt Evidence-based Practice Center used to develop this comprehensive evidence report on the treatment of depression after traumatic brain injury (TBI). We first describe our strategy for identifying articles relevant to our key questions (KQs), our inclusion/exclusion criteria, and the process we used to abstract relevant information from the eligible articles and generate our evidence tables. We also discuss our criteria for grading the quality of individual articles and for rating the strength of the evidence as a whole. Finally, we describe the peer review process.

## Literature Review Methods

### Inclusion Criteria

Our inclusion criteria were developed in consultation with the Technical Expert Panel (TEP) to capture the literature most tightly related to the key questions. Criteria are summarized below.

Table 1 Inclusion and exclusion criteria for treatment of depression after traumatic brain injury

Category | Criteria
Study population | Adults age ≥16 years old
Study settings and geography | Developed nations: United States, Canada, United Kingdom, Western Europe, Japan, Australia, New Zealand, Israel, South America
Publication languages | English only
Admissible evidence (study design and other criteria) | [underlined: Admissible designs] Randomized controlled trials, cohorts with comparison, case-control, and case series (n ≥ 50) [underlined: Other criteria]; - Original research studies that provide sufficient detail regarding methods and results to enable use and adjustment of the data and results; - Patient populations must include participants that have been diagnosed with depression following a traumatic brain injury received in adulthood; - Studies must address one or more of the following for depression after traumatic brain injury:; ○ Treatment modality; ○ Symptom management approach; ○ Short- and long-term outcomes and quality of life; - Relevant outcomes must be able to be abstracted from data presented in the papers

We limited the review to studies published in developed countries to better approximate the United States health care system in terms of access to screening and treatment services. We did not have translation services available to us to review non-English papers, and our TEP agreed that the vast majority if not all of the relevant literature would be published in English. Furthermore, this review is intended to inform U.S. health care, and most research in this population is published in studies. Empirical evidence on the potential for bias created by excluding non-English studies also suggests little effect.24 All study designs except individual case reports were included in order to be inclusive and identify all possible prevalence, screening, and treatment studies. The decision to require at least 50 participants in each study was made in concert with our TEP, and resulted in the exclusion of only 36 studies, of which one was a randomized controlled trial. The adult trauma population is defined at the Level I trauma center as 16 years old or older. Short- and long-term outcomes in traumatic brain injury in children is pathologically distinct from the adult population.25 We chose to limit this study to the adult population of traumatic brain injury and outcomes associated with depression. In order to ascertain prevalence and to further assess potential modifiers of likelihood of being depressed, it was important that studies use an acceptable means of diagnosing depression. We accepted a structured clinical interview or any validated diagnostic tool, excluding for these questions any studies that relied only on self-report of depressed status or that did not describe their approach to depression diagnosis.

Additional criteria. In order to answer KQ1, studies had to provide some measure of prevalence. We excluded studies that did not provide prevalence data (e.g., for which only mean depression scores were available).

In order to answer KQ2, studies had to provide data that allowed prevalence to be assessed in accordance with a specific timeframe, setting, or tool (or some combination of these). Studies that did not provide any information about when depression screening took place relative to injury were excluded from the weighted average for depression prevalence calculations for specific time points.

In order to answer KQ3, we required that studies present data on comorbid psychiatric conditions within the depressed population separately from the nondepressed population, as our intent was not to measure these conditions in the general TBI population but to explain their specific relationship to depression.

This review focused on the prevalence of diagnosed depression in populations that had sustained a documented traumatic brain injury, and on the treatment of those populations. We excluded studies of individuals with penetrating head injuries because penetrating injury, such as gunshot wounds, create specific and severe tissue damage along the course of the injury as well as associated bleeding and inflammation. The mechanism of injury associated with blunt force trauma to the head more often leads to a diffuse pattern of injury that may affect the entirety of the brain. Although long-term outcomes may be similar in some penetrating head injury cases, our focus on the more global nature of blunt-force trauma and its consequences lead us to exclude studies of penetrating head injuries from this review.

### Literature Search and Retrieval Process

Databases. Our search included examination of results in five databases: MEDLINE via the PubMed interface, the PsycINFO database of psychological and psychiatric literature, Embase, the Cumulative Index to Nursing and Allied Health Literature (CINAHL), and the Published International Literature on Traumatic Stress (PILOTS) database. We also hand-searched the reference lists of relevant articles to identify additional citations for review.

Search terms. Controlled vocabulary terms served as the foundation of our search in each resource, complemented by additional keyword terms and phrases selected to represent each of the key concepts in the search. We also employed indexing terms when possible to exclude undesired publication types (e.g., reviews, case reports, letters, etc.) and articles published in languages other than English.

Tables 2–6 outline our search terms and results yielded by each of the databases. Our searches were executed between March and May 2010. From PubMed, we identified 1,491 items for further review; PsycINFO yielded 319 items; Embase yielded 213 items; CINAHL yielded 109 items; and PILOTS yielded 116 citations. After eliminating duplicate citations, 2,015 citations comprised our pool of citations for review.

Table 2 PubMed search strategies (last updated June 2009)

Search # | Terms
#1 | (Brain Concussion[mh] OR brain injuries[mh:noexp] OR Brain Hemorrhage, Traumatic[mh] OR Epilepsy, Post-Traumatic[mh] OR Head Injuries, Closed[mh] OR Head Injuries, Penetrating[mh] OR Intracranial Hemorrhage, Traumatic[mh] OR Craniocerebral Trauma[mh] OR TBI[tiab] OR head injuries[tiab] OR head injury[tiab] OR traumatic brain injury[tiab] OR traumatic brain injuries[tiab] OR neurotrauma[tiab] OR diffuse axonal injury[mh] OR diffuse axonal injury[tiab] OR brain trauma[tiab] OR head trauma[tiab])
#2 | Depressive Disorder[mh] OR Depression[mh] OR depressive[tiab] OR depression[tiab] OR depressed[tiab] OR sadness[tiab] OR sad[tiab] OR hopelessness[tiab] OR suicidal[tiab] OR suicide[tiab] OR Mental Disorders[mh:noexp] OR mood[tiab]

* Numbers do not total due to exclusions in more than one category (15 items were indexed as both letter and case report, 2 as comment and case report, 33 as review and case report, 4 as editorial and comment, 12 as letter and comment, 1 as review and comment, and 2 as editorial and review).

Table 3 PsycINFO search strategies

Search # | Terms
#1 | DE=(“head injuries” or “brain concussion” or “traumatic brain injury”) or KW=(“head injury” or “head injuries” or “traumatic brain injury” or “traumatic brain injuries” OR “craniocerebral trauma” or neurotrauma or “brain trauma” OR “head trauma” OR TBI)
#2 | DE=(“depression emotion” or “major depression” or “hopelessness” or “sadness” or “suicidal ideation” or “suicide”) or KW=(depressive or sad or hopeless or sadness)
#3 | #1 AND #2 AND LA=(English) AND PO=(Human)

* Denotes number of citation retrieved from peer-reviewed journals

Table 4 Embase search strategies

Search # | Terms
#1 | head injury/ or brain concussion/ or brain contusion/ or diffuse axonal injury/ or postconcussion syndrome/ or traumatic brain injury/ or (“craniocerebral trauma” or “brain trauma” or “head trauma” or TBI or “traumatic brain injury” or “traumatic head injury” or “traumatic brain injuries” or “traumatic head injuries”).ab. or (“craniocerebral trauma” or “brain trauma” or “head trauma” or TBI or “traumatic brain injury” or “traumatic head injury” or “traumatic brain injuries” or “traumatic head injuries”).ti.
#2 | mental disease/ or mood disorder/ or depression/ or major depression/ or suicidal ideation/ or hopelessness/ or (depressive or sad or sadness or hopeless).ti. or (depressive or sad or sadness or hopeless).ab.
#3 | 1 and 2 and english.lg. and human/

Table 5 CINAHL search strategies

Search # | Terms
S1 | (“traumatic brain injury”) or (MH “Brain Injuries+”) OR “neurotrauma” OR “brain injuries” OR “TBI” OR “concussion” OR “head injuries” OR “head injury” OR “head trauma” OR “brain trauma”
S2 | ((MH “Depression+”) OR “depressive disorder” OR “sadness” OR “depressed” OR (MH “Suicide”) or (MH “Suicide, Attempted”) or (MH “Suicidal Ideation”) OR “suicide” OR “hopelessness” or (MH “Hopelessness”) OR “mood”)
S3 | S1 AND S2 AND LA English
S4 | S3 AND Exclude MEDLINE Records

Table 6 PILOTS search strategies

Search # | Terms
#1 | (DE=“head injuries”) or (“brain concussion” OR concussion OR “traumatic brain injury” OR “TBI” OR neurotrauma OR “traumatic brain injuries” OR “head trauma” OR “craniocerebral trauma” OR “brain injury” OR “brain injuries” )
#2 | (DE=“depressive disorders”) or (depression OR depressed OR depressive OR suicidal OR suicide OR sadness OR hopelessness)
#3 | #1 AND #2 AND LA=(English)
#4 | #3, limited to peer-reviewed journals

Methods for developing weighted averages for depression prevalence. The following processes were applied in order to select studies to be used in developing the prevalence histograms in the results section of KQ2:

#### Prevalence

- If a study was longitudinal with time since injury greater than 12 months and several followup measures sequentially following initial measure, the study was then included in the spreadsheet duplicate times for each time period (e.g., 2 years, 5 years, 10 years) under the “>12 months” column.
- If a study included different tools with prevalence measure for each, the study was included in the spreadsheet multiple times, once for each tool.

#### Glasgow Coma Scale (GCS)

- If a study listed mean GCS score with percentages accounting for each severity group, the study was listed as including all TBI severity groups.
- If a study listed no GCS score, the study was not included in severity analysis.
- If a study did not provide data by TBI severity category, but provided an overall mean and range instead, the study was considered to include participants in each severity grouping representing in the range, and the study contributed to the analysis of each severity level (e.g., GCS mean 8.0 ± 3.0, range 4–13, then TBI severity groups would be mild to severe, and all TBI severity groups would be included in the spreadsheet).

#### Setting

- Setting was extracted from evidence tables.

In addition, studies that explicitly evaluated approaches to diagnosing depression in TBI populations were included for the second part of KQ2. Studies for this subsection were required to compare at least two tools for assessing depression and provide some statistical means of assessing validity and/or reliability.

For KQ3, we required that studies present data on comorbid psychiatric conditions within the depressed population separately from the nondepressed population as our intent was not to measure these conditions in the general TBI population, but to explain their specific relationship to depression.

Categorization of TBI measures for reporting. For the purpose of reporting results, we prioritized discussion of papers that adequately described severity levels of TBI in the patient population. Ideally these are defined by criteria endorsed by professional organizations, including Glasgow Coma Scale, Centers for Disease Control and Prevention, World Health Organization, and American Congress of Rehabilitation Medicine criteria. Studies in which TBI was defined using an ad hoc approach or by patient self-report are presented in Appendix C.

Categorization of depression diagnoses. In part due to the heterogeneity in both etiology and expression of depression, descriptions in the literature vary from a strict Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition definition of Major Depressive Disorder diagnosed via a Structured Clinical Interview for DSM-IV (SCID) to a positive response to a simple inquiry asking if the patient has ever felt depressed after their injury. For purposes of the review, therefore, we considered participants to be depressed if they were designated as such by the authors of the studies, and endeavored to document the definition used within each study.

Identifying duplicate populations. Because the same study population can be used to do multiple analyses, we developed an algorithm to identify distinct research populations for inclusion in prevalence calculations. We referred to sets of papers that used the same study population as “families” and attempted to identify the “parent” study to provide a representative prevalence estimate.

Most straightforward, of course, were those families of papers in which references were provided that detailed explicitly the relationship between the individual studies, allowing us to identify the parent paper. When such references were not provided, we used a multistep process to cluster papers and then a thorough review of methods and results to identify overlapping or identical populations. Papers were initially clustered by country, then by authors and author affiliations, and potential sets examined together. Within the potential sets of families, we assessed inclusion and exclusion criteria, screening methods, and settings of these studies. In a second step, population descriptors such as average time from injury, age, and population size were examined for identical measures across multiple papers. Of note, it is altogether possible for these characteristics not to match in family papers, particularly in the case of longitudinal studies in which sequential analyses were conducted over time.

Within sets of publications identified as families, individual papers were designated as a “parent” or “child” paper for the purposes of abstracting prevalence data. We attempted to designate the most complete paper as the parent, which meant that it may not have been the earliest or latest publication from the dataset. Factors that played into this determination included assessment of depression as the main outcome, population size (larger populations over smaller populations), inclusion of prevalence information, and inclusion of results over different time periods. Using this approach, we identified 81 unique populations: 62 single studies and 19 parent studies. The 16 parent studies included 34 associated child studies.

Only parent studies were included in summary tables and prevalence calculations for Key Questions 1 and 2. Families are identified in Appendix C, Evidence Tables, with notes in the author field referring to associated studies. Studies utilizing clearly identical populations were combined into a single evidence table when possible.

## Grey Literature Search Methods

We conducted a review of the literature for depression in the context of TBI through a systematic search of resources likely to retrieve grey literature and fugitive information items (Appendix A). Resources were chosen for their relevance to the topic and for their utility in locating unpublished or nontraditional information.

### Search of the Grey Literature

We adapted our approach to the published literature for this survey of grey information sources with selected terms related to TBI and depression. Each database and resource searched (Appendix A) has unique features and characteristics that were utilized to improve sensitivity and specificity of our retrieval.

Utilizing the search engine Google, our team searched the Internet using a combination of keywords to identify technical reports and other relevant data. We used the limit “allintext:” to retrieve only information with our keywords included on the Web page and the feature “site: .gov,.org,.edu,.mil” to limit our search to only Web pages from those designations. U.S. and international government resources and registries were employed to locate current clinical trial protocols and newly funded research projects. Given their strength in indexing unpublished resources, PsycINFO, a psychology and psychiatry database, and BIOSIS Previews, a biosciences database, were used to locate current conference proceedings, dissertations, and other grey literature sources. As a means to improve precision of the search strategy, we limited our retrieval to dissertations, meeting abstracts/papers, technical reports, and conference proceedings. To improve the depth of our grey literature review, our team explored several other resources that did not retrieve any additional information.

## Literature Synthesis

### Development of Evidence Tables and Data Abstraction Process

The staff members and clinical experts who conducted this review jointly developed the evidence tables. We designed the tables to provide sufficient information to help readers understand the studies and determine their quality; we gave particular emphasis to essential information related to our KQs, especially the need to appropriately design evidence tables for prevalence versus treatment studies. We based the format of our evidence tables on successful designs used for prior systematic reviews.

The team was trained to abstract by abstracting several articles into evidence tables and then reconvening as a group to discuss the utility of the table design. We repeated this process through several iterations until we decided that the tables included the appropriate categories for gathering the information contained in the articles. All team members shared the task of initially entering information into the evidence tables. Another member of the team also reviewed the articles and edited all initial table entries for accuracy, completeness, and consistency. The two abstractors reconciled disagreements about the information reported in the evidence tables. The full research team met regularly during the article abstraction period and discussed global issues related to the data abstraction process. In addition to outcomes related to treatment effectiveness, we abstracted all data available on harms. Harms encompasses the full range of specific negative effects, including the narrower definition of adverse events.

The final evidence tables are presented in their entirety in Appendix C. Studies are presented in the evidence tables alphabetically by the last name of the first author. When possible, studies resulting from the same study population were grouped into a single evidence table. A list of abbreviations and acronyms used in the tables appears at the beginning of that appendix.

Two reporting conventions for describing studies in the evidence table were adopted that warrant explanation, namely those for study design and setting of the study. For settings, we allowed five options, with the operating principle being that the setting should reflect the entity from which the participants were drawn, as this can be a reflection to some degree of injury severity, acuity, or the reason that the individuals were seeking care and thus were identified for the study:

- Tertiary care: academic medical centers and tertiary care hospitals
- Trauma center(s)
- Psychiatric/specialty center(s): psychiatry clinic, disability programs
- Rehabilitation center(s)
- Other: community, private practice, prison, nonacademic Veterans Affairs (VA) facility

Study designs for this review were somewhat more difficult, as “standard” study design definitions for systematic review are most often based on reviews of the treatment literature, and our primary focus was necessarily (due to a paucity of treatment studies) on assessment of prevalence. In this case, we were reviewing studies that may, for example, have been intended as cohort studies in populations with TBI and exposure groups other than depression. The characteristic used to define the cohorts in the study was not relevant for our review, but because the authors captured data on prevalence of depression in the study population, we were able to include the study. Therefore, for our purposes we defined studies in which a group of individuals was systematically described as having a TBI and then “sorted” through diagnosis into depressed and nondepressed groups to be cohort studies, even if there were other exposure groups or no groups defined by the authors. These cohorts could be retrospective or prospective based on the usual definitions about when data were collected. We also allowed for the usual definition of randomized controlled trials for the treatment portion of the review and for cross-sectional studies, in which participants were identified at one time point with no longitudinal collection of data.

### Assessing Methodological Quality of Individual Studies

We developed our approach to assessing the quality of individual articles based on our prior experience with conducting systematic reviews. In particular, we used distinct quality rating approaches for the studies used to measure prevalence and those for treatment.

Quality as it relates to prevalence studies is largely a function of appropriately identifying, defining, and enumerating the target population in which prevalence is to be measured. Prevalence estimates may be biased if the study population included has higher or lower rates of the outcome (in this case, depression) than does the population to which the prevalence estimate is intended to apply. Therefore, we based our quality assessment of prevalence studies on the authors’ appropriateness in defining both TBI and depression (including tools used for measurement), in their provision of descriptive information about the TBI (such as mechanism and severity), their followup and retention methods including ability to not lose participants to followup (which would bias estimates if depressed individuals either were or were not lost to followup at different rates from nondepressed individuals). Therefore, we used eight primary questions with some subquestions to assess quality of the prevalence literature.

#### Prevalence Studies

Definition of TBI. Because no single definition of TBI is consistently used in the literature, we worked with our clinical experts to develop a list of “best” approaches to defining or diagnosing TBI. Studies had to use one of these in order to be awarded the highest quality score under this criterion. Studies that specified an operational definition that was not included on the list of “best” definitions were given one plus. A complete lack of definition, or self-report (i.e., no evidence of clinical diagnosis) received a minus.

Severity of TBI. The severity of TBI is known to influence the trajectory of recovery and is thought to affect the risk of post-TBI depression. Therefore, studies should provide measures of TBI severity for included participants.

Definition of Depression. As with the definition of TBI, we worked with clinical experts to categorize and rank approaches to diagnosing depression. The full categorization is provided below, and for quality purposes we applied the following:

- Was a clinical scale or operational definition provided?
- ++ = SCID or other structured interview by a trained mental health care provider such as a physician, psychologist, etc.
- + = Operational definition or scale provided, but not a structured interview
- − = Other definition, self-report, or not reported (NR)

Table 7 Categorization of depression measures for reporting

Category A | SCID or other structured interview by a clinician (e.g., physician or psychologist)
Category B | Validated instruments other than clinical interview, including HAM-D, BDI, HADS, CES-D, NFI, or SCL-90
Category C | Other definition, self report, ad hoc, chart review, or no definition provided

Participant selection. For measuring prevalence and comparing studies of prevalence, it is necessary to clearly identify the population from which the cases arise. Therefore, we required that investigators clearly describe the participants, including the source, and that this description be adequate such that another researcher could create a comparable study population.

Sampling and screening methods. We used a three-part approach to assessing appropriate sampling and screening methods, requiring first that the pool of potentially eligible participants be clearly enumerated, second that the number meeting eligibility requirements be provided, and third that the number of participants at onset and conclusion of the study (if applicable) also be provided.

Loss to followup. For longitudinal studies, we assessed the proportion of participants still in the study at completion. We expected less than 25 percent loss for high quality, between 25 and 50 percent for good quality, and studies that lost more than 50 percent of participants received a low quality (minus) score for this variable.

Two potentially important characteristics of participants that could affect prevalence are prior history of psychological conditions (i.e., psychological conditions in the post-TBI period may not be new onset) and time since injury. Therefore, for adequate quality we required that information on both of these be provided by the authors. We did not specify what information or the degree of information needed.

Treatment studies. For treatment studies, we assessed creation and comparability of comparison groups (selection bias), loss to followup and dropout (attrition bias), statistical analysis, including evidence of adequate power, and external validity (also known as applicability).

Internal validity. The criteria for assessing internal validity were as follows:

Randomized allocation to treatment. This assessment combines randomization and method of randomization into a single criterion with a three-point scale.

Rationale. By randomly assigning groups to the intervention of interest, other factors that may confound the results are equally distributed between groups (assuming a large enough sample size). This equal distribution minimizes the chances of over- or underestimation of treatment effect based on unequal distribution of confounding factors. If randomized, we also evaluated the study for randomization methods, using the rationale described in Matchar and colleagues, 2001.^26^ “Pseudo-randomization” methods may be susceptible to bias, as demonstrated by evidence of unequal distribution of subject characteristics27 and larger effect sizes compared with studies using more rigorous methods.28 In addition, methods of allocation concealment are also important in preventing bias (e.g., use of prepared sealed envelopes).

We combined these elements into a single operational definition, as described below:

Operational definition. Criterion met if randomization methods were not susceptible to bias, such as computer-generated numbers in sealed sequentially numbered envelopes (+). Criterion not met by studies that either used methods more prone to bias, such as alternate medical record numbers, or did not describe randomization methods or methods of allocation concealment (−). Criterion not applicable if treatment was not randomly allocated (NA).

Masking.

Rationale. Masking, also known as blinding, refers to the concealment of treatment allocation from the care provider, the assessor, and the patient. In certain trials, particularly surgical trials, masking the patient or the surgeon from the treatment allocation can be challenging or impossible. Similarly, masking the assessor assigned to record immediate postprocedural outcomes such as wound healing can also be difficult. Nevertheless, when possible, masking prevents expectations from influencing findings.

Operational definition. Criterion was met if assessors and participants were masked to treatment or group (+). Criterion was not met if care provider, assessor, or patient were not masked (−). Criterion not applicable if treatment was not randomly allocated (NA).

Adequate description of patients and control selection criteria.

Rationale. Patient characteristics that might affect outcomes (such as severity of symptoms, duration of symptoms, failure of prior treatment, or medical comorbidities) are likely to differ between two interventions. If these differences are not characterized, then erroneous conclusions may be drawn.

Operational definition. Criterion met if inclusion and exclusion criteria for participation in the study were well described.

We expected that the study population should be adequately described to make clear the potential for confounding in the analysis. We expected the study authors to adequately describe the study population such that it could theoretically be reproducible by another investigator. We expected comparable methods to be used to identify and screen participants across exposure or treatment groups.

Description of loss to followup.

Rationale. Failing to account for patients lost to followup may lead to erroneous conclusions, especially if the loss to followup is related to either the underlying disease or the intervention (i.e., patients seeking care elsewhere because of continuing symptoms or unacceptable side effects of treatment).

Operational definition. Criterion met for adequate followup (+) if (a) loss to followup was explicitly reported and (b) no more than 20 percent of any study arm was lost to followup. Those studies with less than 10 percent lost to followup were given an extra (+). Studies with greater than 20 percent lost to followup were considered inadequate for this measure (−).

Description of dropout rates.

Rationale. Dropout rates may reflect differences in clinically important variables, such as side effects or treatment response. Failure to account for dropouts may result in erroneous conclusions similar to those seen with failure to account for loss to followup.

Operational definition. Criterion met if (a) patients dropping out of the study prior to completion were reported and (b) no more than 20 percent in any study arm left the study for reasons related to the study intervention or withdrawal of consent. Those studies with less than 10 percent dropout were given an extra (+). Studies with greater than 20 percent dropout were considered inadequate for this measure (−).

Power calculation provided.

Rationale. Many studies, especially case series, lack sufficient power to detect clinically important differences in outcomes or patient characteristics.

Operational Definition. Criterion met if a power calculation (pre or post) was provided.

Recognition and description of statistical issues.

Rationale. Use of inappropriate tests may lead to misleading conclusions. For example, variables such as depression scores are often not normally distributed; use of means instead of medians when data may be affected by outlying observations can be misleading.

Operational definition. Criterion met if (a) appropriate statistical tests were used (e.g., nonparametric methods for variables with nonnormal distributions, or survival analysis techniques to account for loss to followup and dropouts) and (b) potential study limitations regarding design and analysis were discussed. Criterion not met if (a) inappropriate statistical tests were used or (b) study limitations were not discussed. An intention-to-treat analysis was required of clinical trials.

External validity. The criteria for assessing external validity were as follows:

Baseline characteristics: We created a composite score for adequacy of the description of baseline characteristics. We expected the severity of the TBI and time since the TBI event to be presented. If either of these were omitted, criteria were not met.

## Strength of Available Evidence

Strength of evidence is typically assigned to reviews of medical treatments after assessing four domains: risk of bias, consistency, directness, and precision.29 Although these categories were developed for assessing the strength of treatment studies, the domains apply also to studies of prevalence and screening. Available evidence for each key question was assessed for each of these four domains; the domains were combined qualitatively to develop the strength of evidence for each key question.

We graded the body of literature for each key question and present those ratings as part of the discussion in Chapter 4. The possible grades were:

I. High: High confidence that the evidence reflects the true effect. Further research is unlikely to change estimates.
II. Moderate: Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
III. Low: Low confidence that the evidence reflects the true effect. Further research is likely to change confidence in the estimate of effect and is also likely to change the estimate.
IV. Insufficient: Evidence is either unavailable or does not permit a conclusion.

## External Peer Review

As is customary for all systematic evidence reviews done for the Agency for Healthcare Research and Quality (AHRQ), this report was reviewed by a wide array of individual outside experts in the field, including our TEP, and from relevant professional societies and public organizations. AHRQ also requested review from its own staff. The Scientific Resource Center sent 8 invitations for peer review. Reviewers included clinicians (e.g., trauma surgeons, military and combat physicians, physical medicine and rehabilitation physicians, and psychiatrists), representatives of federal agencies, advocacy groups, and potential users of the report.

The Scientific Resource Center charged peer reviewers with commenting on the content, structure, and format of the evidence report, providing additional relevant citations and pointing out issues related to how we had conceptualized and defined the topic and KQs. We also asked reviewers to complete a peer review checklist. The Scientific Resource Center received 4 responses in addition to comments from AHRQ staff. The individuals listed in Appendix E gave us permission to acknowledge their review of the draft. We compiled all comments and addressed each one individually, revising the text as appropriate.