# Introduction

We do not know the extent to which depression contributes to long-term disability following traumatic brain injury (TBI). Depression is one of several potential psychiatric illnesses that are common following TBI. Major depression may be triggered by physical or emotional distress, and it can deplete the mental energy and motivation needed for both recovering from the depression itself and adapting to the physical, social, and emotional consequences of trauma with brain injury. Depression may be masked by other deficits after head injury, such as cognitive changes and flat affect, which may be blamed for lack of progress in post-trauma treatment but actually reflect underlying depression. Clinicians, caregivers, and patients lack formal evidence to guide the timing of depression screening, which tools to use for screening and assessment, treatment choices, and assessment of treatment success.

## Importance of Depression

Depression is defined by criteria that likely circumscribe a heterogeneous set of illnesses. While no single feature is seen in all depressed patients, common features include sadness, persistent negative thoughts, apathy, lack of energy, cognitive distortions, nihilism, and inability to enjoy normal events in life. Especially in a first episode, individuals and families may not recognize the changes as part of an illness, making identification and self-reporting of the condition challenging. Active screening is essential to recognition, treatment, and prevention of recurrence.

The most salient consequence of depression is suicide. Suicide is usually impulsive and extremely difficult to predict and prevent. At least half of suicides occur in the context of a mood disorder. Depression reduces quality of life, impairs ability to function in social and work roles, causes self-doubts and difficulty taking action, all of which can delay recovery from TBI. The Diagnostic and Statistical Manual for Mental Disorders, Fourth Edition (DSM-IV-TR) defines the illness in terms of physiologic disturbances of sleep, appetite, attention and concentration, motor activity, and energy, and of psychological losses of interest in normal activities, hope, and self-worth while ruminating with excessive sadness, guilt, and suicidal thoughts. The disturbances may also occur following TBI due to other circumstances, such as pain that disrupts sleep, which may mask the recognition that the sleep disturbance is also a part of a burgeoning depression. Depression may be financially costly in undermining physical therapy efforts, treatment compliance in general, and rehabilitation planning and efforts. The need for systematic evaluation of the prevalence and consequences of depression following TBI is imperative, given the potential for mitigating suicide and unnecessary disability.

## Overview of Traumatic Brain Injury (TBI)

TBI occurs when external force from events such as falls, assault, motor vehicle accidents, or blasts injures the brain. It may occur as a result of a direct hit to the head, or from rapidly accelerating and decelerating wind accompanied by pressure changes that can injure the brain directly or propel other objects into the head (as from a blast).1 TBI is often accompanied by symptoms that may be severe or mild, and in cases of mild TBI (mTBI) can include nausea, headache, balance problems, blurred vision, memory loss, or difficulty concentrating.2

### Impact of TBI

The Centers for Disease Control and Prevention (CDC) estimates that 1.5 million nonmilitary individuals in the United States sustain a traumatic brain injury each year.3 Because these estimates are based on hospital utilization data, and some individuals with mild TBI likely do not seek any care or seek care in other settings, they probably underestimate the impact of TBI, particularly in the presence of sports-related injury. They also do not include TBI that occurs in the military setting. Nonetheless, estimates of direct and indirect costs associated with TBI exceed $56 billion and may be increasing.4 Among individuals who sustain a TBI, approximately 50,000 die each year of their injuries and 80,000 to 90,000 have a long-term disability. Traumatic brain injuries are considered mild, moderate, or severe and are categorized using the Glasgow Coma Scale (GCS); a GCS score of 13–15 is considered mild, 9–12 moderate, and 3–8 severe. Most TBIs are mild, and CDC estimates that 75 percent of civilian TBI falls into this category (Available at: http://www.cdc.gov/ncipc/pub-res/mtbi/mtbireport.pdf).5 Because of this, many TBIs likely remain unreported and untreated.

### Military TBI

Traumatic brain injury is more common in the military than in civilian populations, even in peacetime. Within the military, the risk for TBI varies among specialties. Paratroopers, for example, are reported to be at higher risk for TBI.6 Over the past decade, advances in body protection systems have resulted in fewer deaths among combat forces, but a concomitant rise in TBI has been observed.1 Indeed, prevalence of combat-related brain injuries in forces active in Iraq and Afghanistan appears higher than in any prior conflict. Among patients with combat-related injuries at Walter Reed Army Medical Center from 2003 to 2005, 30 percent had sustained a TBI.7 A major cause of TBI in the current conflicts is blast injury, in which injuries occur as a result of changes to atmospheric pressure, objects hitting people as a result of the blast, or people being thrown against objects.8 Unlike the civilian population, however, the military population has a higher rate of moderate and severe TBI (56 percent) than mild TBI.8

### Civilian TBI

Outside of the military theater, TBIs are most commonly associated with falls (28 percent), motor vehicle traffic accidents (20 percent), being struck by objects (19 percent), and assault (11 percent).9 Much of the research in the nonmilitary population, especially on mild TBI, is derived from the sports injury literature. Because athletes tend to represent a healthier subpopulation, this literature may not be entirely applicable to the general population of individuals who sustain a TBI. However, it is likely the most robust source of information on TBI in civilians in general.

### Relationship of TBI to Postinjury Psychiatric Conditions

TBIs are associated with a range of short- and long-term sequelae, including physical, cognitive, behavioral, and emotional outcomes.10 Symptoms of depression appear common in individuals who have sustained a TBI, with estimates of post-TBI depression ranging from 15 percent to 77 percent in the published literature.11–13 Depression associated with TBI can manifest shortly after injury or well into the future,14–15 and rates reported are likely affected by timing of screening and tools used. In their review of TBI rehabilitation, in which they selected studies from MEDLINE via the PubMed interface^®^, the Cumulative Index to Nursing and Allied Health Literature, and PsycINFO, Gordon and colleagues identified 74 studies addressing psychiatric functioning after a TBI.16 Their assessment was that TBI is associated with high rates of depression (up to more than half of cases) and other DSM Axis I and Axis II conditions, including paranoid, schizoid, and avoidant personalities. Furthermore, depression was noted to be comorbid with other psychiatric conditions, including addiction or anxiety, in a number of studies.

Depression diagnosed postinjury is thought to be a product of multiple biopsychosocial factors, including neuroanatomical or pathophysiological changes (i.e., brain lesions and specific location of lesions) and psychosocial factors such as concerns about disability or poor functional status.14,17

Mechanism for post-TBI depression and implications for treatment. The exact mechanism by which individuals with TBI are at greater risk for depression is not known, although several causes seem possible. For example, mechanisms of post-TBI cellular injury include apoptosis and necrosis.18 It seems likely that such mechanisms would affect the presentation and treatment of depression. For example, a self-reported history of blast exposure was associated with more headache and tinnitus than nonblast exposure injury mechanisms, but depression rates were similar (respectively, 21.2 percent for n = 156 vs. 15.8 percent for n = 38, p = 0.65).19

Lesion types and locations also may be important, but since pharmacologic treatments address widespread network phenomena, they simultaneously target function in multiple regions, suggesting that choice of medical treatment may depend more on potential harms than the mechanism that causes the depression. Cognitive therapy may be contra-indicated in the presence of severe concomitant cognitive deficits, as it is in depression of nontraumatic etiology, but this assumption has yet to be empirically examined in the TBI population. Other psychotherapy model selections may turn out to depend more on cognitive capacity, psychologicalmindedness and emotional lability than on the involvement of specific biological lesions or magnitude of psychosocial factors.

Timing of depression onset. Clinical care providers and families need to know when and how to screen TBI patients for depression. However, literature on the timing of depression onset should be interpreted carefully, since decisions about when and how to conduct screening within the study could bias results. Intuitively, early-onset depressions might seem more likely to have a neuroanatomic source, while later onset might be presumed to be related to patients’ realizations of impairment severity and limitations that are likely to become persistent. These differences could influence interpretation of timing and methods of depression screenings, if indeed earlier screening captures the “neurobiological” depressions and misses the later onsets of “situational” reactions associated with ongoing treatments, complications, or unyielding plateaus in improvement.

Premorbid conditions and TBI. Also of concern is the way in which preinjury status may have affected both the likelihood of sustaining an injury and the future risk of depressive disorder. For example, the relationship observed between alcohol use or abuse and TBI may be circular in that preinjury use can increase the risk of injury but may also be related to an increased risk of psychiatric sequelae when an injury does occur. Other factors, such as demographics and support systems in place prior to injury may also confound relationships between injury and depression, and may also affect the perceived need for screening, the criteria for diagnosis, diagnostic elements, goal-setting, and successful assessments with treatment.17

Diagnosing depression in patients with TBI. Significant overlap between the brain regions associated with the core symptoms of depression and those that are often damaged in TBI (especially frontal lobe lesions), makes accurate diagnosis of depression challenging. Symptoms of postconcussion syndrome (PCS), which is common after TBI, may include: cognitive deficits, disordered sleep, irritability, aggression, anxiety, depression, changes in personality, affective lability, and apathy or lack of spontaneity. Many of these symptoms are also commonly present in a variety of mental disorders, such as unipolar and bipolar mood disorders and anxiety disorders. Therefore, it can be difficult to distinguish, especially in a single diagnostic interview, if these symptoms truly reflect an independent psychiatric disorder or whether they are better understood as simply additional symptoms of TBI or PCS.20 Longer periods of observation may be needed to assess the degree to which an intrinsic variability of post-TBI symptoms over time is associated with, or dissociated from, the sadness and disinterest that is considered a hallmark characteristic of depression. Additionally, atypical presentations of depression are anticipated in the TBI population, where paradoxical laughter may appear in lieu of tears to express sadness. Furthermore, the timing of the assessment may affect whether depression is suspected or preliminarily identified. Reviews should address questions of how and when depression might best be assessed.

## Treatment Options

This review focuses specifically on depression following TBI and the treatment of depression in this context (i.e., not the treatment of the TBI per se). Treatment options for depression after a TBI theoretically include the range of psychotropic medications, including selective serotonin reuptake inhibitors, serotonin and norepinephrine reuptake inhibitors, tricyclic antidepressants, monoamine oxidase inhibitors, and other, non-FDA approved uses of both older and novel medications, as well as psychotherapy, neuropsychological rehabilitation, community-based rehabilitation, complementary and alternative medicine and neuromodulation therapies (electroconvulsive therapy and others) that may be routinely or only recently applied to the treatment of non-TBI associated depressions. Decisions about treatment approach may be affected by the clinician’s understanding of the etiology of the initial injury as well as issues of timing of onset of the depression and concomitant conditions.21 As with nonpsychotic, unipolar depression in the general population,22–23 in TBI an evidence-based modality of psychotherapy would be a first option with the option to initiate antidepressant medications concomitantly or in sequence.

Treatment harms, including well-recognized side effects, may also be of particular concern in this population because systematic evidence for most medications is generally available only for intact, depressed but otherwise healthy individuals. For example, many psychotropic medications can lower the seizure threshold in a population already potentially predisposed to seizure due to TBI. When patients do have seizure disorders or other TBI-related outcomes, they may already be on medication and therefore at risk for potential drug–drug interactions. Other side effects, such as gastrointestinal distress or weight gain, may also occur in this population, and it is not clear if they may occur at lower doses than in the noninjured population. In patients who present with apathy associated with TBI that is misdiagnosed as depression, antidepressants can sometimes worsen this symptom just as they do in the non-TBI depressed population by causing emotional blunting.21

## Key Questions and Analytic Framework

### Key Questions

We synthesized evidence in the published literature to address these key questions:

KQ1 What is the prevalence of depression after traumatic brain injury, and does the area of the brain injured, the severity of the injury, the mechanism or context of injury, or time to recognition of the traumatic brain injury, or other patient factors influence the probability of developing incident clinical depression?
KQ2 When should patients who suffer traumatic brain injury be screened for depression, with what tools, and in what setting?
KQ3 Among individuals with TBI and depression, what is the prevalence of concomitant psychiatric/behavioral conditions, including anxiety disorders, post-traumatic stress disorder, substance abuse, and major psychiatric disorders?
KQ4 What are the outcomes (short and long term, including harm) of treatment for depression among traumatic brain injury patients utilizing psychotropic medications, individual/group psychotherapy, neuropsychological rehabilitation, community-based rehabilitation, complementary and alternative medicine, neuromodulation therapies, and other therapies?
KQ5 Where head-to-head comparisons are available, which treatment modalities are equivalent or superior with respect to benefits, short- and long-term risks, quality of life, or costs of care?
KQ6 Are the short- and long-term outcomes of treatment for depression after TBI modified by individual characteristics, such as age, pre-existing mental health status or medical conditions, functional status, and social support?

## Analytic Framework for TBI and Depression

The context in which diagnosis and treatment of depression occurs for individuals after TBI is complex. Our analytic framework emphasizes that care takes place at the interface of the health care system and the individual (Figure 1). The pathway through care is indicated in the boxes along the center line where the person and care meet. Each key question is indicated within the framework at the relevant point of influence in care. Each of the domains listed among individual and system factors, such as demographics, social support, provider factors, and health care coverage status, has been shown to influence care trajectories and outcomes across a range of conditions. Making these domains explicit as they surround and influence the care pathway provides the framework in which the review team and technical expert panel conducted this review. To the degree that individuals or care settings vary in context-specific points of influence, the literature may not always be applicable. We recognized for TBI and depression that there is a dearth of literature for a large portion of these domains and aimed to focus where expert guidance felt evidence was most likely. Overall, we sought to examine factors within the central care pathway as well as in selected contextual domains such as setting (a portion of KQ2), psychiatric comorbidities that could complicate care (KQ 3), and influence of individual characteristics on outcomes as a step toward enhancing applicability of the results (KQ 6).

Figure 1 Analytic framework for TBI and depression

Figure 1 places the key questions on an analytic framework showing the essential decisional points between traumatic brain injury and response to treatment for depression. The analytic framework emphasizes that care takes place at the interface of the health care system and the individual. The pathway through care is indicated in the boxes along the center line where the person and care meet. Each key question is indicated within the framework at the relevant point of influence in care. After experiencing a traumatic brain injury, an individual may be screened for depression at some point. The timing and method of screening constitute one aspect of the research question for this review. Individuals with a diagnosis of depression may then be treated with one or more of the following: psychotropic medications, individual/group psychotherapy, neuropsychological and community-based rehabilitation, CAM, or neuromodulation therapies. Use of these treatments may result in short and long-term outcomes such as change in symptom status, harms, need for additional treatment, improvements in quality of life and activities of daily living, and recurrence of symptoms. An individual's risk of both traumatic brain injury and depression are influenced by demographics, such as age, gender, and occupation. In addition, timing of treatment of the traumatic brain injury, screening and treatment of depression, as well as the outcomes of treatment are influenced by timing of care initiation, severity of TBI and any concomitant physical injuries, presence of social support, and mental status. Provider factors, such as specialty and experience, the content of the care received, insurance coverage, and organization of services related to treatment for both the TBI and depression also influence screening, treatment, and outcomes.

Portions of the framework that are unexplored in the scientific literature are highlighted in the considerations of future research needs.

### Organization of This Evidence Report

Chapter 2 describes our methods, including our search strategy, inclusion and exclusion criteria, approach to review of abstracts and full publications, extraction of data into evidence tables, and compilation of evidence. We also describe the approach to grading the quality of the literature and to describing the strength of the literature.

Chapter 3 presents the results of the evidence report by key question, synthesizing the findings across treatment type. We report the number and type of studies identified, and we differentiate between total numbers of publications and unique studies to bring into focus the number of duplicate publications in this literature in which multiple publications are derived from the same study population. Chapter 4 discusses the results in Chapter 3 and enlarges on methodologic considerations relevant to each key question. We also outline the current state of the literature and challenges for future research on depression after TBI.

### Technical Expert Panel (TEP)

We identified technical experts on the topic of traumatic brain injury and depression in the fields of trauma surgery, neurology, psychiatry, psychology, military/wartime health care, and patient advocacy to provide assistance during the project. The TEP (see Appendix E) was expected to contribute to the Agency for Healthcare Research and Quality’s broader goals of (1) creating and maintaining science partnerships as well as public-private partnerships and (2) meeting the needs of an array of potential customers and users of its products. Thus, the TEP was both an additional resource and a sounding board during the project. The TEP included seven members serving as technical or clinical experts. To ensure robust, scientifically relevant work, we called on the TEP to provide reactions to work in progress and advice on substantive issues or possibly overlooked areas of research. TEP members participated in conference calls and discussions through e-mail to:

- Refine the analytic framework and key questions at the beginning of the project;
- Discuss the preliminary assessment of the literature, including inclusion/exclusion criteria;
- Provide input on the information and categories included in evidence tables;
- Develop a hierarchy of participant characteristics and outcomes to systematically assess;
- Advise about the clinical availability, use, and most common doses for therapeutics.

Because of their extensive knowledge of the literature, including numerous articles authored by TEP members themselves, and their active involvement in professional societies and as practitioners in the field, we also asked TEP members to participate in the external peer review of the draft report.

## Uses of This Report

This report is intended to describe the extent to which depression occurs after TBI, appropriate timing and methods for diagnosis, and available evidence for treatment. It should be of use to groups and individuals who treat patients with traumatic brain injury, such as research and clinical psychiatrists; psychologists; physiatrists; trauma surgeons; neurologists; speech, occupational, and physical therapists; and primary care physicians. In particular, evidence in the report could be used to prioritize need for depression screening of those patients. Of particular importance is the role of this report in guiding future research by identifying current gaps, particularly in the treatment literature, given the near absence of research on treatment for depression in TBI-affected populations. Future research recommendations could be helpful to investigators, funders and policymakers, with the goal of advancing understanding of the causes, natural history, and most effective care of individuals with depression after TBI.