# Future Research

## State of the Literature

The amount of literature about TBI is increasing rapidly, with the focus on the relationship between TBI and depression also growing. As is typical of advancing areas of research, early publications about TBI and depression have been predominantly cross-sectional, with little apparent consensus about measures or key covariates and a high degree of variability in quality of publications.

Prospective studies of sufficient size to enable multivariate modeling of predictors of outcome or analysis of outcome by factors such as severity are rare. Likewise, studies that are prospective in the sense that they include repeated measures of depression are few. Often studies meet criteria for prospective investigation by enumerating patients at the time of injury and counting time elapsed until followup as the prospective component. However, with a single measure of depression at one time of followup, this data is in essence cross-sectional and cannot contribute to understanding the natural history of the onset and course of depression after TBI.

Achieving representative study populations is challenging and rarely achieved because enumerating the entire population eligible for followup is hampered by the portion of the population who do not seek care for head injury. While studies in specialized settings like neuropsychiatric clinics or rehabilitation programs can be applicable to estimating risk in those settings, they cannot be generalized to base the population of all those with injuries.

Overall, the content of the current literature is fair to poor, with a preponderance of study designs that do not provide strong evidence. As a result, the strength of the literature is low for understanding the predictors, natural history, treatment options, and modifiers of outcomes of depression that follows TBI. Strength is moderate for establishing that depression is common and exceeds the prevalence expected in the general population.

Concerning deficits in research methods. As a body of literature a number of concerning deficits were recurring. Less than 12 percent of included studies met criteria for good quality. For example, many publications lacked one or more of the following:

- Operational definitions using standard approaches to diagnosing and categorizing severity of TBI.
- Description of the method of enumerating potentially eligible TBI participants.
- Timeframe in which participants were accrued.
- Report of the proportion of potentially eligible individuals who could be contacted and those who agreed to enroll.
- Analysis of any difference between those reached and enrolled and those not reached and/or who declined enrollment.
- Analysis of dropout and loss to followup.
- Uniform time from injury at followup.
- Non-TBI comparison groups.
- Description of the validity and reliability of methods used to measure depression.
- Sufficient detail about the cutoffs used to assign categories of depression severity from screening scales.
- Collection of crucial covariates that should be investigated as candidate predictors or direct risk factors for developing depression after TBI such as other psychiatric comorbidity, level of disability, cognitive function, and level of self-awareness.
- Collection of crucial covariates to assess potential confounding of the relationship between TBI and depression, such as litigation status.
- Stratification of findings to help understand how characteristics such as severity of injury or age contribute to depression risk
- Use of multivariate models in populations large enough to incorporate factors that confound and modify the relationship between TBI and depression risk.
- Masking of assessors to TBI status to prevent potential for overdiagnosing depression because TBI is thought to be associated with depression.
- Statement of hypotheses and power calculations.

Gaps in knowledge. Five of the six key questions for this report could not be adequately answered with existing literature, and the question about prevalence was only partially satisfied. The key questions were derived with expert and stakeholder input to define core knowledge for which we should have information. The questions themselves can serve as an outline for critical areas in which knowledge is insufficient. Lack of studies to assess how best to identify and treat depression after TBI is disconcerting. High-quality research is warranted across the spectrum of study designs and aims which includes:

- Collaborative studies in which multiple sites form networks to enumerate and followup large and more representative populations.
- Documentation of the natural history of onset and the course of depression after TBI.
- Investigation of the predictors of depression with emphasis on understanding etiology and better targeting of clinical resources.
- Direct comparison of screening tools and their yield in common clinical care settings for those with history of TBI including primary care practice.
- Intervention studies assessing the efficacy and effectiveness of the leading therapeutic modalities for depression.
- Head-to-head comparison of those found effective to assess comparative risks, benefits, and costs.
- Investigation of preventive interventions to decrease risk of onset of depression.
- Study of the value of educational interventions for those injured and their support networks to assist in detection of depression and in enhancing supports to mitigate negative effects on quality of life and function.