# Conclusions

Overall, the content of the current literature is fair to poor, with a preponderance of study designs that do not provide strong evidence. As a result, the strength of the literature is low for understanding the predictors, prevalence, natural history, treatment options, and modifiers of outcomes of depression that follows TBI. Nonetheless, considerable evidence suggests depression after all forms and severity of TBI is common.

We find a concerning lack of high-quality evidence to inform clinical decisionmaking for the 1 million to 2 million individuals in the United States who experience TBI each year. Lack of treatment studies focused on this populations is especially remarkable. Given how common, concerning, and debilitating the combination of TBI and depression can be, a priority on promoting high-quality research in the United States is imperative.