# Grey Literature Results

## Government and Nonprofit Publications

1. New Zealand Guidelines Group (NZGG). Traumatic brain injury: diagnosis, acute management and rehabilitation. Wellington (NZ): New Zealand Guidelines Group (NZGG); 2006 Jul. 240 p.
  http://www.guideline.gov/summary/summary.aspx?doc_id=10281&nbr=5397&ss=6&xl=999#s24
2. Invisible Wounds of War. Psychological and Cognitive Injuries, Their Consequences, and Services to Assist Recovery (RAND Report) http://www.dtic.mil/cgibin/GetTRDoc?AD=ADA494242&Location=U2&doc=GetTRDoc.pdf
3. Gulf War and Health – IOM Report
  http://www.nap.edu/catalog.php?record_id=12436#toc
4. Fann JR, Hart T, Schomer KG. Treatment for Depression Following Traumatic Brain Injury: A Systematic Review. J Neurotrauma August 2009; ePub(ePub): ePub.
  http://dx.doi.org/10.1089/neu.2009.1091

## Nonpublished Research Opportunities and Current Projects

1. Psychological Health and Traumatic Brain Injury Advanced Technology/Therapeutic Development Award
  http://www.grants.gov/search/search.do;jsessionid=bhWpKXcVBKCT2l7LKyvlBjxz2QW4T8GXpWKn6rS8rg5dzVgXQdhH!-1757398871?oppId=48392&mode=VIEW
2. Treatment strategy to prevent mood disorders following traumatic brain injury. PI: Ricardo Estiban Jorge. ICD: National Institute of Neurological Disorders & Stroke. Grant Number: 5R01NS055827-02
  http://projectreporter.nih.gov/project_info_description.cfm?aid=7596417
  Project start date: 2008-04-01
  Project end date: 2013-03-31
3. Telephone and In-Person Cognitive Behavioral Therapy for Depression After Traumatic Brain Injury. PI: Jesse R. Fann, MD, MPH. Grant Number: H133G070016
  http://www.naric.com/research/record.cfm?search=1&type=all&criteria=braininjuriesdepression&phrase=no&rec=1751
  Start Date: October 1, 2007
  End Date: October 1, 2010
4. Effectiveness of a Group Cognitive-Behavioral Intervention for Depression after TBI and Factors that Affect Response to Treatment. PI: Allison Clark. Grant Number: H133G070222
  http://www.naric.com/research/record.cfm?search=1&type=all&criteria=braininjuriesdepression&phrase=no&rec=1772
  Start Date: October 1, 2007
  End Date: October 1, 2010
5. Post Traumatic Brain Injury (TBI) Depression, PI Information: Rao, VA. ICD: National Institute of Mental Health. Grant Number: 5K23MH066894-05
  Project Start: 01-AUG-2004
  Project End: 31-JUL-2009
6. Phone Cognitive Behavioral Therapy for Depression after Traumatic Brain Injury, PI Information: Fann, JR. ICD: Eunice Kennedy Shriver National Institute of Child Health and Human Development. Grant Number: 5R21HD053736-02
  Project Start: 15-SEP-2007
  Project End: 31-AUG-2009
7. Neuropsychiatry of Traumatic Brain Injury, PI Information: Kraus, MF. ICD: University of Illinois at Chicago. Grant Number: 5K23MH068787-05
  Project Start Date: 1-APR-2008
  Project End Date: 31-MAR-2010

## Clinical Trial Protocols

1. Mindfulness-Based Cognitive Therapy Intervention to Treat Depression in Individuals with a Traumatic Brain Injury Conditions: Depression; Traumatic Brain Injury Intervention: Behavioral: Mindfulness-Based Cognitive Therapy NCT ID: NCT00745940 Start Date: March 2009
2. Treatment Strategy to Prevent Mood Disorders Following Traumatic Brain Injury Condition: Traumatic Brain Injury Interventions: Drug: Placebo; Drug: Sertraline NCT ID: NCT00704379 Start Date: June 2008
3. Treatment of Post-TBI Depression Conditions: Traumatic Brain Injury; Depression Interventions: Behavioral: Cognitive behavioral therapy; Behavioral: Supportive psychotherapy NCT ID: NCT00211835 Start Date: November 2005
4. The Effect of Exercise on Mood After Traumatic Brain Injury Conditions: Traumatic Brain Injury Depression Interventions: Behavioral: Aerobic exercise Behavioral: No exercise NCT ID:NCT00571545
5. Pharmacological Intervention in Depression After Traumatic Brain Injury Conditions: TBI (Traumatic Brain Injury) Interventions: Drug: Venlafaxine NCT ID: NCT00205491
6. Depression and Traumatic Brain Injury Conditions: Depression Traumatic Brain Injury Interventions: Drug: citalopram (celexa) NCT ID: NCT00254007
7. TMS in the Treatment of the Sequelae of Closed Brain Injury Conditions: Depression; Closed Head Injury, Interventions: Device: rTMS; Device: Sham rTMS Start Date: October 2007 NCT ID: NCT00531258
8. Behavioral Activation for Posttraumatic Stress Disorder (PTSD)/ Depression Treatment in Operations Iraqi Freedom and Enduring Freedom (OIF/OEF) Veterans, Conditions: Posttraumatic Stress Disorder; Depression, Interventions: Behavioral Activation treatment; Other: Usual VA Treatment for PTSD, Start Date: May 2009 NCT ID: NCT00805532
9. Improving Psychological Wellness After Acquired Brain Injury Conditions: Depression;Anxiety;Brain Injury, Intervention: Cognitive Behavioural Therapy Start Date: June 2008, NCT ID: NCT00866632
10. The use of Motivational Interviewing and cognitive behavioural therapy to treat anxiety and/or depression following traumatic brain injury, Conditions: Traumatic Brain Injury, Depression, Anxiety, Intervention: Cognitive Behavioural Therapy (CBT), Start Date: June 2008, Registry Number: ACTRN12609000456257

## Conference Proceedings

1. Mauri MC, Colasanti A, Paletta S, et al. Post traumatic brain injury major depression and primary major depression: psychopathological and neuropsychological profiles. Twentysecond Congress of the European College of Neuropsychopharmacology; 2009 September 12–16; Istanbul, Turkey. European Neuropsychopharmacology 2009 Sep;19(Suppl. 3):S389.
2. Thaut MH, Gardiner JC., Holmberg D, et al. Neurologic music therapy improves executive function and emotional adjustment in traumatic brain injury rehabilitation. Conference on the Neurosciences and Music III; 2008 June 25–28; Montreal, Canada. In; Dalla Bella S, Kraus N, Overy K, et al, eds. Neurosciences and Music III: Disorders and Plasticity. Hoboken, N.J.: Wiley-Blackwell; 2009. p. 406–416.
3. Colasanti A, Mauri MC, Paletta S, et al. Primary major depression versus post-traumatic brain injury major depression: psychopathological and neuropsychological differences. Twenty-First Congress of the European College of Neuropsychopharmacology;,2008 August 30–September 3; Barcelona, Spain. European Neuropsychopharmacology 2008 Aug;18(Suppl. 4):S582–S583.
4. Mauri MC, Colasanti A, Natoli A, et al. Psychiatric and neuropsychological sequelae of TBI: a case-control, longitudinal study. Twenty-Sixth Collegium Internationale Neuro-Psychopharmacologicum Congress (CINP); 2008 July 13–17; Munich, Germany. International Journal of Neuropsychopharmacology 2008 Jul;11(Suppl. 1):308.
5. Hou, J-GG, Lai E. Previous traumatic brain injury may be a risk factor of mood disorders in Parkinson’s disease. Sixtieth Annual Meeting of the American Academy of Neurology; 2008 April 12–19; Chicago. Neurology 2008 Mar 11;70(11, Suppl. 1):A438.
6. Lee H, Kim S, Kim J, et al. Comparing effects of methylphenidate, sertraline and placebo on depressive symptoms and psychomotor function in patients with traumatic brain injury. Twenty-fourth CINP Congress; 2004 June 20–24; Paris. International Journal of Neuropsychopharmacology 2004 Jun;7(Suppl. 2):S274.
7. Buzzi M,G, Bivona U, Matteis M, et al. Cognitive and psychological patterns in posttraumatic headache following severe traumatic brain injury. Eleventh Congress of the International Headache Society (IHC); 2003 September 13–16; Rome. Cephalalgia 2003 September;23(7):672.
8. Jordan BD, Glass E, Ortega-Verdejo K. Assessment of neuropsychiatric symptoms in patients with traumatic brain injury. Fifty-Fourth Annual Meeting of the American Academy of Neurology; 2002 April 13–20; Denver. Neurology 2002 April 9;58(7 Supplement 3):A357.
9. Van Den Eeden SK, Tanner CM, Popat RA, et al. The risk of Parkinson’s disease associated with head injury and depression: a population-based case-control study. Fifty-Second Annual Meeting of the American Academy of Neurology; 2000 April 29–May 6; San Diego. Neurology 2000 April 11;54(7 Supp. 3):A347.
10. Holtzer R, Burright RG, Donovick PJ. Depression and brain injury history of psychiatric patients. Twenty-Eighth Annual Meeting of the Society for Neuroscience, Part 1; 1998 November 7–12; Los Angeles.. Society for Neuroscience—Abstracts 1998;24(1–2):740.
11. Warden DL, Dougherty DS, Quintero-Sheeley E, et al. Psychotic symptoms following moderate traumatic brain injury. Fourty-Sixth Annual Meeting of the American Academy of Neurology; 1994 May 1–7; Washington, DC Neurology 1994;44(4 Suppl 2):A401.
12. Rao N. Suicide after successful rehabilitation of traumatic brain injury. Fifty-Third Annual Assembly of the American Academy of Physical Medicine and Rehabilitation and the Sixty-Eighth Annual Session American Congress of Rehabilitation Medicine; 1991 October 27–31; Washington, DC. Arch Phys Med Rehabil 1991;72(10):818.
13. Van Mier H, Hulstijn W, Tromp E, et al. Fine motor performance in closed head injury and depression. Twentieth Annual Meeting of the Society for Neuroscience; 1990 October 28–November 2; St. Louis, Missouri. Soc Neurosci Abstr 1990;16(2):1317.
14. O’Brien KP. Relationship of psychosocial and physical dysfunction to emotional adjustment after traumatic brain injury. Sixteenth Annual International Neuropsychological Society Meeting; 1988 January 27–30. Journal of Clinical and Experimental Neuropsychology 1988;10(1):41–42.

## Dissertations

1. Anderson SS. The effect of written emotional expression on depression following mild traumatic brain injury: A pilot study [dissertation]. Philadelphia: Drexel University; 2009.
2. Wegner RC. Spirituality and religion as predictors of mood and quality of life following traumatic brain injury [dissertation]. Boston: Massachusetts School of Professional Psychology; 2008.
3. Shepherd JG Jr. Coping style as mediator of health-related quality of life and depression after an acquired brain injury [dissertation]. Santa Barbara: Fielding Graduate University; 2007.
4. Fenimore EA. Depression following traumatic brain injury and the hamilton depression rating scale [dissertation]. Palo Alto: Pacific Graduate School of Psychology; 2006.
5. Bay EH. Chronic stress, cortisol regulation, interpersonal relatedness, cognitive burden, and depressive symptoms among community-dwelling survivors of brain injury [unpublished dissertation]. Ann Arbor, MI: University of Michigan; 2002.
6. Sinacori DR. Depression in a brain-injured sample: An investigation of indicators on the Rorschach and MMPI-2 [dissertation]. Chester, PA: Widener University; 1999.
7. Ruttan LA. Depression and neuropsychological functioning in mild traumatic brain injury [dissertation]. Toronto: York University; 1998.
8. Burg JS. Psychiatric treatment outcome following traumatic brain injury [dissertation]. Binghamton, NY: State University of New York at Binghamton; 1997.
9. Statman SH. The evolution of depression over the first two years post head trauma [dissertation]. Philadelphia, PA: Temple University; 1987.
10. Mervak TA. Physical and psychological factors in depression following closed head trauma [dissertation]. Boston: Boston University; 1979.