# Peer Reviewers

Nancy Carney, Ph.D.

Assistant Professor, Department of Medical Informatics and Clinical Epidemiology

Oregon Health & Science University

Portland, Oregon

James Chesnutt, M.D.

Pediatrics, Orthopedics & Rehabilitation, and Family Medicine

Oregon Health & Science University

Portland, Oregon

Col. Geoffrey Ling, M.D., Ph.D. *

* Also served on Technical Expert Panel (TEP)

Program Manager

Defense Advanced Research Projects Agency

Arlington, Virginia

David Moore, M.D., Ph.D.

Scientific Advisor, Traumatic Brain Injury

Defense Centers of Excellence for Psychological Health and Traumatic Brain Injury

Arlington, Virginia