# Excluded Studies

1 Late effects of torture. Lancet. 09. 28. 1968;2(7570):721-2. X-1.
2 Sequelae of head injuries. Med Sci Law. 07. 1968;8(3):188-99. X-1, X-2, X-4, X-5. [pmid: 5686684].
3 Depressed fracture of the skull. J Iowa Med Soc. 07. 1969;59(7):589-91. X-1. [pmid: 5791245].
4 Editorial: Boxing brains. Lancet. 11. 10. 1973;2(7837):1064-5. X-3. [pmid: 4127317].
5 Editorial: The psychiatric sequelae of head injury. Med J Aust. 11. 10. 1973;2(19):873-4. X-3. [pmid: 4765869].
6 A study of the utilisation of skull radiography in 9 accident-and-emergency units in the U.K. A national study by the Royal College of Radiologists. Lancet. 12. 6. 1980;2(8206):1234-6. X-1. [pmid: 6108403].
7 Subdural haematoma--hygroma. Z Kinderchir. 10. 1981;34(2):156-78. X-1. [pmid: 7331538].
8 Patient selection for skull radiography in uncomplicated head injury. Lancet. 01. 15. 1983;1(8316):115-8. X-1. [pmid: 6129426].
9 Headaches common, but not ordinary: of tension and trauma part 4. Emergency Medicine. 10. 15. 1984;16(17):153-5. 159. 163. 4. X-1, X-2, X-5.
10 Which of the following selection criteria predict positive results on computed tomography scans for patients with traumatic head injury? Focal neurologic deficit. Alcohol intoxication. Depressed sensorium. Can Fam Physician. 09. 1994;40:1540. 1543. X-1, X-2, X-4, X-5. [pmid: 7920047].
11 Revised medical criteria for evaluating mental disorders and traumatic brain injury. Social Security Administration. Final rules. Fed Regist. 08. 21. 2000;65(162):50746-83. X-1, X-2. [pmid: 11067731].
12 Horizons. Journal of Neuroscience Nursing. 02. 2001;33(1):65-6. X-2.
13 From the Centers for Disease Control and Prevention. Injuries and illnesses among New York City Fire Department rescue workers after responding to the World Trade Center attacks. JAMA. 10. 2. 2002;288(13):1581-4. X-1. [pmid: 12362915].
14 Injuries and illnesses among New York City Fire Department rescue workers after responding to the World Trade Center attacks. MMWR Morb Mortal Wkly Rep. 09. 11. 2002;51(Spec No):1-5. X-1.
15 Field notes. Physician & Sportsmedicine. 06. 2003;31(6):13. X-2. [pmid: 20086486].
16 Migraine, chronic daily headache, and primary headache: clinical characteristics, epidemiology, and comorbidity. Headache: The Journal of Head & Face Pain. 06. 2004;44(6):628-32. X-1.
17 The neurological burden of the war in Iraq and Afghanistan. Ann Neurol. 10. 2006;60(4):A13-5. X-1, X-2. [pmid: 17068792].
18 Pediatrics. Pediatrics. 07. 2006;118(1):365. X-2.
19 RI: was organic mood disorder compensable?: Workers’ Compensation Court stops benefits. Nurs Law Regan Rep. 01. 2006;46(8):3. X-1.
20 In brief. Occupational Health. 11. 2007;59(11):7. X-2.
21 In case you haven’t heard. Mental Health Weekly. 06. 11. 2007;17(23):8. X-1, X-2.
22 News briefs. Psychiatric Times. 03. 2007;24(3):9. X-2.
23 Product update. Journal of Psychosocial Nursing & Mental Health Services. 07. 2007;45(7):54. X-2.
24 Traumatic brain injury diagnosis, acute management and rehabilitation : evidence-based best practice guideline summary. [Internet Resource; Computer File Date of Entry: 20070525]. 2007; 2007(May 28):1 electronic document (36 p.).X-7
25 2008 SNRS abstracts -- F - G. Southern Online Journal of Nursing Research. 2008;8(4):5. X-2.
26 Abstracts. Annals of Epidemiology. 09. 2008;18(9):708-41. X-2.
27 Company liable to pay compensation for suicide following workplace accident. Occupational Health. 04. Occupational Health Review. 2008;60(4):34. X-1.
28 Gulf War and health. Volume 7, Long-term consequences of traumatic brain injury. [Internet Resource Date of Entry: 20090126]. 2008:xii, 376 p. : digital, PDF file, ill.X-7
29 Minerva. BMJ: British Medical Journal. 10. 25. 2008;337(7676):1004. X-1, X-2.
30 Specialty briefs. NurseWeek. 07. 28. 2008;15(15):22-3. X-1, X-2.
31 Specialty briefs. Nursing Spectrum—Florida Edition. 2008;18(15):20-21. X-1, X-2.
32 Splinters and fragments. Injury Prevention. 06. 2008;14(3):216. X-2.
33 A head injury can have a devastating effect on a person’s mental health. Ment Health Today. 05. 2009:33. X-2.
34 Splinters and fragments. Injury Prevention. 04. 2009;15(2):144. X-2.
35 Abbassioun K, Amirjamshidi A, Rahimizadeh A. Spontaneous intrauterine depressed skull fractures. Childs Nerv Syst. 1986;2(3):153-6. X-1. [pmid: 3779672].
36 Abraham D, Colussi V, Shina D, et al. TBI treatment planning using the ADAC pinnacle treatment planning system. Med Dosim. Winter. 2000;25(4):219-24. X-1. [pmid: 11150693].
37 Achte K, Jarho L, Kyykka T, et al. Paranoid disorders following war brain damage. Preliminary report. Psychopathology. 1991;24(5):309-15. X-1. [pmid: 1784707].
38 Achte KA, Ginman L. Suicidal attempts with narcotics and poisons. Acta Psychiatr Scand. 1966;42(2):214-32. X-1. [pmid: 5958543].
39 Adeloye A, Odeku EL. The nervous system in sickle cell disease. Afr J Med Sci. 01. 1970;1(1):33-48. X-1. [pmid: 4329947].
40 Adeloye A, Shokunbi MT. Immediate bone replacement in compound depressed skull fractures. Cent Afr J Med. 04. 1993;39(4):70-3. X-1. [pmid: 8306388].
41 Aderet A. Alert: the dark side of chats--internet without boundaries. Isr J Psychiatry Relat Sci. 2009;46(3):162-6. X-1, X-2. [pmid: 20039515].
42 Afari N, Harder LH, Madra NJ, et al. PTSD, combat injury, and headache in veterans returning from Iraq/Afghanistan. Headache. 10. 2009;49(9):1267-1276. X-1. [pmid: 19788469].
43 Agelink MW, Andrich J, Postert T, et al. Relation between electroconvulsive therapy, cognitive side effects, neuron specific enolase, and protein S-100. J Neurol Neurosurg Psychiatry. 09. 2001;71(3):394-6. X-1. [pmid: 11511718].
44 Ahmad R, Orakzai S. Rabies and vaccination failure: Two case reports. Pakistan Journal of Medical Sciences. 2002;18(4):325-327. X-1, X-2.
45 Ahmed M. Inquiry into suicide bid by Feltham inmate that left him brain-damaged. Community Care. 2006;15(1648):8. X-5.
46 Aizer A, Lowengrub K, Dannon PN. Kleptomania after head trauma: Two case reports and combination treatment strategies. Clinical Neuropharmacology. 2004;27(5):211-215. X-1, X-2, X-5. [pmid: 15602100].
47 Al-Adawi S, Dorvlo AS, Burke DT, et al. Apathy and depression in cross-cultural survivors of traumatic brain injury. J Neuropsychiatry Clin Neurosci. Fall. 2004;16(4):435-42. X-4. [pmid: 15616169].
48 al-Adawi S, Powell JH, Greenwood RJ. Motivational deficits after brain injury: a neuropsychological approach using new assessment techniques. Neuropsychology. 01. 1998;12(1):115-24. X-1, X-5. [pmid: 9460739].
49 Albanese J, Arnaud S, Rey M, et al. Ketamine decreases intracranial pressure and electroencephalographic activity in traumatic brain injury patients during propofol sedation. Anesthesiology. 12. 1997;87(6):1328-34. X-1. [pmid: 9416717].
50 Alberti A, Sarchielli P, Mazzotta G, et al. Event-related potentials in posttraumatic headache. Headache. 06. 2001;41(6):579-85. X-5. [pmid: 11437894].
51 Alden PB, Svingen BA, Deutschman CS, et al. Essential fatty acid status in isolated closed head injury. J Trauma. 09. 1987;27(9):1039-43. X-1, X-5. [pmid: 3656466].
52 Alderfer BS, Arciniegas DB, Silver JM. Treatment of depression following traumatic brain injury. Journal of Head Trauma Rehabilitation. 11–12. 2005;20(6):544-562. X-1, X-2, X-4, X-5. [pmid: 16304490].
53 Alderson L, Watson T, Main E. Assessment of dynamic walking balance in children with acquired brain injury. Physical Therapy Reviews. 2007;12(1):3-20. X-1.
54 Alemdar M, Iseri P, Yalug I, et al. Route learning impairment associated with encephalomalasia secondary to traumatic brain injury: A case report. Applied Neuropsychology. 2008;15(2):150-155. X-1, X-2, X-5. [pmid: 18568608].
55 Alexander DA, Kemp RV, Klein S, et al. Psychiatric sequelae and psychosocial adjustment following ocular trauma: a retrospective pilot study. Br J Ophthalmol. 05. 2001;85(5):560-2. X-1, X-5. [pmid: 11316717].
56 Alexander L. Hypnosis in primarily organic illness. American Journal of Clinical Hypnosis. 1966;8(4):250-253. X-5. [pmid: 5909202].
57 Alfano DP, Neilson PM, Fink MP. Long-term psychosocial adjustment following head or spinal cord injury. Neuropsychiatry, Neuropsychology, & Behavioral Neurology. 04. 1993;6(2):117-125. X-1, X-5.
58 Al-Haddad SA, Kirollos R. A 5-year study of the outcome of surgically treated depressed skull fractures. Ann R Coll Surg Engl. 05. 2002;84(3):196-200. X-1. [pmid: 12092875].
59 Alias A, Krishnapillai R, Teng HW, et al. Head injury from fan blades among children. Asian J Surg. 07. 2005;28(3):168-70. X-1, X-3, X-5. [pmid: 16024308].
60 Allen EA. Interventions for postconcussion syndrome. Trauma. 2007;9(3):181-187. X-1, X-2, X-4, X-5.
61 Allen JG. Review of “Does stress damage the brain? Understanding trauma-related disorders from a mind-body perspective.”. Bulletin of the Menninger Clinic. Spr. 2004;68(2):189-190. X-2.
62 Allen JG. Review of “Does stress damage the brain? Understanding trauma-related disorders from a mind-body perspective.”. Bulletin of the Menninger Clinic. Spr. 2004;68(2):189-190. X-1, X-2, X-5.
63 Almenar Bonet L. Spanish Heart Transplantation Registry. 20th official report of the Spanish Society of Cardiology Working Group on Heart Failure and Heart Transplantation 1984–2008. Rev Esp Cardiol. 11. 2009;62(11):1286-96. X-1. [pmid: 19889340].
64 Almogy G, Mintz Y, Zamir G, et al. Suicide bombing attacks: Can external signs predict internal injuries. Ann Surg. 04. 2006;243(4):541-6. X-1. [pmid: 16552207].
65 Aloni A, Keren O, Cohen M, et al. Incidence of sexual dysfunction in TBI patients during the early post-traumatic in-patient rehabilitation phase. Brain Inj. 02. 1999;13(2):89-97. X-1, X-5. [pmid: 10079954].
66 Alper K, Schwartz KA, Kolts RL, et al. Seizure incidence in psychopharmacological clinical trials: an analysis of Food and Drug Administration (FDA) summary basis of approval reports. Biol Psychiatry. 08. 15. 2007;62(4):345-54. X-1, X-4, X-5. [pmid: 17223086].
67 Alper M, Totan S, Cankayali R, et al. Gunshot wounds of the face in attempted suicide patients. J Oral Maxillofac Surg. 08. 1998;56(8):930-3. discussion 933–4. X-1, X-5. [pmid: 9710186].
68 Alpert E, Seigerman C. Steroid withdrawal psychosis in a patient with closed head injury. Archives of Physical Medicine & Rehabilitation. 1986;67(10):766-769. X-1, X-2, X-5. [pmid: 3767629].
69 Al’tman Ya A, Balonov L, Deglin VL, et al. Role of the dominant and nondominant hemispheres in the organization of spatial hearing. Hum Physiol. 01–02. 1981;7(1):7-13. X-1. [pmid: 7275125].
70 Ambrozic J, Bunc M, Osredkar J, et al. S100B protein in benzodiazepine overdose. Emerg Med J. 02. 2008;25(2):90-2. X-1. [pmid: 18212144].
71 Amison T, Foster A. Electroconvulsive Therapy in a Middle-Aged Adult With Cortical Atrophy. Journal of ECT. 06. 2005;21(2):122-124. X-1, X-5. [pmid: 15905756].
72 Andelic N, Hammergren N, Bautz-Holter E, et al. Functional outcome and health-related quality of life 10 years after moderate-to-severe traumatic brain injury. Acta Neurol Scand. 07. 2009;120(1):16-23. X-1. [pmid: 18976326].
73 Anderson MI, Parmenter TR, Mok M. The relationship between neurobehavioural problems of severe traumatic brain injury (TBI), family functioning and the psychological well-being of the spouse/caregiver: path model analysis. Brain Inj. 09. 2002;16(9):743-57. X-1. [pmid: 12217201].
74 Anderson SS. The effect of written emotional expression on depression following mild traumatic brain injury: A pilot study. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2009;69(9-B):X-7.
75 Anderson V, Brown S, Newitt H, et al. Educational, vocational, psychosocial, and quality-of-life outcomes for adult survivors of childhood traumatic brain injury. J Head Trauma Rehabil. 09–10. 2009;24(5):303-12. X-1, X-3. [pmid: 19858964].
76 Andersson AL, Bunketorp O. Cycling and alcohol. Injury. 07. 2002;33(6):467-71. X-1. [pmid: 12098540].
77 Andersson S, Krogstad JM, Finset A. Apathy and depressed mood in acquired brain damage: relationship to lesion localization and psychophysiological reactivity. Psychol Med. 03. 1999;29(2):447-56. X-1. [pmid: 10218936].
78 Andrasik F, Wincze JP. Emotional and psychosocial aspects of mild head injury. Semin Neurol. 03. 1994;14(1):60-6. X-1, X-2, X-4, X-5. [pmid: 8029561].
79 Andrews CJ. Further documentation of remote effects of electrical injuries, with comments on the place of neuropsychological testing and functional scanning IEEE. Trans Biomed Eng. 10. 2006;53(10):2102-13. X-1.
80 Andrews M. The woes of the pros. U S News & World Report. 06. 25. 2007;142(23):66. X-2.
81 Andrulonis PA, Glueck BC, Stroebel CF, et al. Borderline personality subcategories. J Nerv Ment Dis. 11. 1982;170(11):670-9. X-1. [pmid: 7119767].
82 Andrulonis PA, Vogel NG. Comparison of borderline personality subcategories to schizophrenic and affective disorders. British Journal of Psychiatry. 04. 1984;144:358-363. X-1, X-5. [pmid: 6722396].
83 Andrykowski MA, Carpenter JS, Greiner CB, et al. Energy level and sleep quality following bone marrow transplantation. Bone Marrow Transplant. 10. 1997;20(8):669-79. X-1. [pmid: 9383231].
84 Andy OJ, Jurko MF, Hughes JR. Amygdalotomy for bilateral temporal lobe seizures. South Med J. 06. 1975;68(6):743-8. X-1, X-2, X-5. [pmid: 806118].
85 Anglin D, Hutson HR, Luftman J, et al. Intracranial hemorrhage associated with tangential gunshot wounds to the head. Acad Emerg Med. 07. 1998;5(7):672-8. X-1. [pmid: 9678390].
86 Anson K, Ponsford J. Coping and emotional adjustment following traumatic brain injury. J Head Trauma Rehabil. 05–06. 2006;21(3):248-59. X-5. [pmid: 16717502].
87 Anson K, Ponsford J. Evaluation of a coping skills group following traumatic brain injury. Brain Inj. 02. 2006;20(2):167-78. X-5. [pmid: 16421066].
88 Anson K, Ponsford J. Who benefits? Outcome following a coping skills group intervention for traumatically brain injured individuals. Brain Inj. 01. 2006;20(1):1-13. X-5. [pmid: 16403695].
89 Anstey KJ, Butterworth P, Jorm AF, et al. A population survey found an association between self-reports of traumatic brain injury and increased psychiatric symptoms. J Clin Epidemiol. 11. 2004;57(11):1202-9. X-1. [pmid: 15567638].
90 Anstey KJ, Jorm AF, Reglade-Meslin C, et al. Weekly alcohol consumption, brain atrophy, and white matter hyperintensities in a community-based sample aged 60 to 64 years. Psychosom Med. 09–10. 2006;68(5):778-85. X-1. [pmid: 17012533].
91 Antin JH, Lee SJ, Neuberg D, et al. A phase I/II double-blind, placebo-controlled study of recombinant human interleukin-11 for mucositis and acute GVHD prevention in allogeneic stem cell transplantation. Bone Marrow Transplant. 03. 2002;29(5):373-7. X-1. [pmid: 11919725].
92 Ariza M, Del Matarin M, Junque C, et al. Influence of angiotensin-converting enzyme polymorphism on neuropsychological subacute performance in moderate and severe traumatic brain injury. Journal of Neuropsychiatry & Clinical Neurosciences. 2006;18(1):39-44. X-1. [pmid: 16525069].
93 Armengol CG. A multimodal support group with Hispanic traumatic brain injury survivors. J Head Trauma Rehabil. 06. 1999;14(3):233-46. X-5. [pmid: 10381976].
94 Armstrong C. Emotional changes following brain injury: psychological and neurological components of depression, denial and anxiety. Journal of Rehabilitation. 04–06. 1991;57(2):15-22. X-2.
95 Armstrong RW, Steinbok P, Cochrane DD, et al. Intrathecally administered baclofen for treatment of children with spasticity of cerebral origin. J Neurosurg. 09. 1997;87(3):409-14. X-1, X-3. [pmid: 9285607].
96 Arnold G, Boone KB, Lu P, et al. Sensitivity and specificity of finger tapping test scores for the detection of suspect effort. Clin Neuropsychol. 02. 2005;19(1):105-20. X-1. [pmid: 15814482].
97 Arnold MC. Rebuilding life after a brain injury: do social comparisons help patients cope?. American University. 2004:92. X-7.
98 Arroyo S. Rufinamide Neurotherapeutics. 2007;4(1):155-162. X-1.
99 Arseni C, Stanciu M. Particular clinical aspects of chronic subdural haematoma in adults. Eur Neurol. 1969;2(2):109-22. X-1, X-5. [pmid: 5802541].
100 Artru F, Philippon B, Flachaire E, et al. A controlled study of Dextran 40: effect on cerebral blood flow and metabolic rates in acute head trauma. Intensive Care Med. 1989;15(8):499-504. X-1. [pmid: 2481692].
101 Asano T, Ohno K, Takada Y, et al. Fractures of the floor of the anterior cranial fossa. J Trauma. 10. 1995;39(4):702-6. X-1. [pmid: 7473959].
102 Ashendorf L, Constantinou M, McCaffrey RJ. The effect of depression and anxiety on the TOMM in community-dwelling older adults. Arch Clin Neuropsychol. 01. 2004;19(1):125-30. X-1. [pmid: 14670385].
103 Asikainen I, Kaste M, Sarna S. Early and late posttraumatic seizures in traumatic brain injury rehabilitation patients: brain injury factors causing late seizures and influence of seizures on long-term outcome. Epilepsia. 05. 1999;40(5):584-9. X-1. [pmid: 10386527].
104 Ates O, Ondul S, Onal C, et al. Post-traumatic early epilepsy in pediatric age group with emphasis on influential factors. Childs Nerv Syst. 03. 2006;22(3):279-84. X-1, X-3. [pmid: 15889309].
105 Atighechi S, Baradaranfar MH, Akbari SA. Reduction of nasal bone fractures: a comparative study of general, local, and topical anesthesia techniques. J Craniofac Surg. 03. 2009;20(2):382-4. X-1. [pmid: 19258905].
106 Atkinson SD. Grieving and loss in parents with a schizophrenic child. Am J Psychiatry. 08. 1994;151(8):1137-9. X-1. [pmid: 8037247].
107 Atteberry-Bennett J, Barth JT, Loyd BH, et al. The relationship between behavioral and cognitive deficits, demographics and depression in patients with minor head injuries. International Journal of Clinical Neuropsychology. 1986;8(3):114-117. X-5.
108 Auerbach V, Jann B. Neurorehabilitation and HIV infection: clinical and ethical dilemmas. J Head Trauma Rehabil. 03. 1989;4(1):23-31. X-1. [pmid: 11659430].
109 Avdibegovic E, Becirovic E, Selimbasic Z, et al. Cerebral cortical atrophy and silent brain infarcts in psychiatric patients. Psychiatr Danub. 06. 2007;19(1–2):49-55. X-1. [pmid: 17603416].
110 Avis SP. Suicidal gunshot wounds. Forensic Sci Int. 06. 28. 1994;67(1):41-7. X-1. [pmid: 8082859].
111 Baandrup L, Jensen R. Chronic post-traumatic headache - A clinical analysis in relation to the International Headache Classification 2nd Edition. Cephalalgia. 2005;25(2):132-138. X-1. [pmid: 15658950].
112 Babin PR. Diagnosing depression in persons with brain injuries: A look at theories, the DSM-IV and depression measures. Brain Injury. 10. 2003;17(10):889-900. X-2, X-5. [pmid: 12963555].
113 Bach LJ, Happe F, Fleminger S, et al. Intact theory of mind in TBI with behavioural disturbance. Brain Cogn. 03. 2006;60(2):196-8. X-1, X-5. [pmid: 16646117].
114 Bachman DL. The diagnosis and management of common neurologic sequelae of closed head injury. Journal of Head Trauma Rehabilitation. 06. 1992;7(2):50-9. X-2.
115 Bach-y-Rita G. Habitual violence and self-mutilation. Am J Psychiatry. 09. 1974;131(9):1018-20. X-1. [pmid: 4413617].
116 Bach-y-Rita G, Veno A. Habitual violence: a profile of 62 men. Am J Psychiatry. 09. 1974;131(9):1015-7. X-1. [pmid: 4413618].
117 Baden MM. Homicide, suicide, and accidental death among narcotic addicts. Hum Pathol. 03. 1972;3(1):91-5. X-1. [pmid: 5060684].
118 Baguley IJ, Cooper J, Felmingham K. Aggressive behavior following traumatic brain injury: how common is common. J Head Trauma Rehabil. 01–02. 2006;21(1):45-56. X-1. [pmid: 16456391].
119 Bahraini NH, Brenner LA, Harwood JE, et al. Utility of the trauma symptom inventory for the assessment of post-traumatic stress symptoms in veterans with a history of psychological trauma and/or brain injury. Mil Med. 10. 2009;174(10):1005-9. X-1. [pmid: 19891210].
120 Bakare CG, Adeloye A. Intellectual deficits in Nigerians after missile wounds of the brain. Brain. 1972;95(1):79-86. X-1, X-5. [pmid: 5023092].
121 Baker EJ, Jay JJ, Philip VM, et al. Ontological Discovery Environment: a system for integrating gene-phenotype associations. Genomics. 12. 2009;94(6):377-87. X-1, X-2. [pmid: 19733230].
122 Baker F, Wigram T, Gold C. The effects of a song-singing programme on the affective speaking intonation of people with traumatic brain injury. Brain Inj. 07. 2005;19(7):519-28. X-1, X-5. [pmid: 16134740].
123 Baker JE. Family adaptation when one member has a head injury. J Neurosci Nurs. 08. 1990;22(4):232-7. X-3. [pmid: 2144558].
124 Baker-Price L, Persinger MA. Intermittent burst-firing weak (1 microTesla) magnetic fields reduce psychometric depression in patients who sustained closed head injuries: a replication and electroencephalographic validation. Percept Mot Skills. 06. 2003;96(3 Pt 1):965-74. X-5. [pmid: 12831278].
125 Baker-Price LA, Persinger MA. Weak, but complex pulsed magnetic fields may reduce depression following traumatic brain injury. Percept Mot Skills. 10. 1996;83(2):491-8. X-5. [pmid: 8902023].
126 Balasubramaniam V, Kanaka TS. Amygdalotomy and hypothalamotomy - a comparative study. Confin Neurol. 1975;37(1–3):195-201. X-1. [pmid: 1093784].
127 Baldo JV, Ahmad L, Ruff R. Neuropsychological performance of patients following mold exposure. Appl Neuropsychol. 2002;9(4):193-202. X-1. [pmid: 12584073].
128 Bamrah JS, Johnson J. Bipolar affective disorder following head injury. British Journal of Psychiatry. 01. 1991;158:117-119. X-5. [pmid: 1673076].
129 Barak A, Verssano D, Halpern P, et al. Ophthalmologists, suicide bombings and getting it right in the emergency department. Graefes Arch Clin Exp Ophthalmol. 02. 2008;246(2):199-203. X-1. [pmid: 17805557].
130 Barber JW, Hundley P, Kellogg E, et al. Clinical and demographic characteristics of 15 patients with repetitively assaultive behavior. Psychiatr Q. Fall. 1988;59(3):213-24. X-1, X-5. [pmid: 3237889].
131 Bardenhagen FJ, Bowden SC, Shields RB, et al. Psychosocial and neuropsychological outcomes in two high-functioning males 20 years after traumatic brain injury. Neurocase. 1999;5(4):325-343. X-2, X-5.
132 Barker-Collo SL. Behavioural profiles and injury severity following childhood traumatic brain injury. Brain Impairment. 05. 2007;8(1):22-30. X-3.
133 Barrett K, Buxton N, Redmond AD, et al. A comparison of symptoms experienced following minor head injury and acute neck strain (whiplash injury). J Accid Emerg Med. 09. 1995;12(3):173-6. X-6. [pmid: 8581240].
134 Barry E, Krumholz A, Bergey GK, et al. Nonepileptic posttraumatic seizures. Epilepsia. 04. 1998;39(4):427-31. X-1, X-4. [pmid: 9578033].
135 Barth JT, Macciocchi SN, Giordani B, et al. Neuropsychological sequelae of minor head injury. Neurosurgery. 11. 1983;13(5):529-33. X-1, X-4. [pmid: 6646380].
136 Baskin JH, Edersheim JG, Price BH. Is a picture worth a thousand words? Neuroimaging in the courtroom. Am J Law Med. 2007;33(2–3):239-69. X-1. [pmid: 17910159].
137 Basson MD, Guinn JE, McElligott J, et al. Behavioral disturbances in children after trauma. J Trauma. 10. 1991;31(10):1363-8. X-3, X-5. [pmid: 1942144].
138 Bateman A, Culpan FJ, Pickering AD, et al. The effect of aerobic training on rehabilitation outcomes after recent severe brain injury: a randomized controlled evaluation. Arch Phys Med Rehabil. 02. 2001;82(2):174-82. X-1, X-5. [pmid: 11239307].
139 Batten SV, Pollack SJ. Integrative outpatient treatment for returning service members. J Clin Psychol. 08. 2008;64(8):928-39. X-1, X-5. [pmid: 18561182].
140 Bauer M, Polzin S, Patzelt D. The use of clinical CCT images in the forensic examination of closed head injuries. J Clin Forensic Med. 04. 2004;11(2):65-70. X-1, X-5. [pmid: 15261000].
141 Bavisetty S, McArthur DL, Dusick JR, et al. Chronic hypopituitarism after traumatic brain injury: risk assessment and relationship to outcome. Neurosurgery. 05. 2008;62(5):1080-93. discussion 1093–4. X-1. [pmid: 18580806].
142 Bay E, Hagerty B, Williams RA, et al. Chronic stress, salivary cortisol response, interpersonal relatedness, and depression among community-dwelling survivors of traumatic brain injury. J Neurosci Nurs. 02. 2005;37(1):4-14. X-1. [pmid: 15794439].
143 Bay E, Kirsch N, Gillespie B. Chronic stress conditions do explain posttraumatic brain injury depression. Res Theory Nurs Pract. Summer-Fall. 2004;18(2–3):213-28. X-1. [pmid: 15553348].
144 Bay E, Sikorskii A, Fuli G. Functional status, chronic stress, and cortisol response after mild-to-moderate traumatic brain injury. Biol Res Nurs. 01. 2009;10(3):213-25. X-1. [pmid: 19015162].
145 Bay E, Sikorskii A, Saint-Arnault D. Sex differences in depressive symptoms and their correlates after mild-to-moderate traumatic brain injury. J Neurosci Nurs. 12. 2009;41(6):298-309. quiz 310–1. X-1. [pmid: 19998681].
146 Bay E, Xie Y. Psychological and biological correlates of fatigue after mild-tomoderate traumatic brain injury. West J Nurs Res. 10. 2009;31(6):731-47. X-1. [pmid: 19502473].
147 Bay EH. Chronic stress, cortisol regulation, interpersonal relatedness, cognitive burden, and depressive symptoms among community-dwelling survivors of brain injury. University of Michigan. 2001:255. X-7.
148 Bay EH. Chronic stress, cortisol regulation, interpersonal relatedness, cognitive burden, and depressive symptoms among community-dwelling survivors of brain injury. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2002;62(10-B):X-7.
149 Bayir A, Kalkan E, Kocak S, et al. Fibrinolytic markers and neurologic outcome in traumatic brain injury. Neurol India. 12. 2006;54(4):363-5. X-1. [pmid: 17114843].
150 Bayside Health. TMS in the Treatment of the Sequelae of Closed Brain Injury, ClinicalTrials.gov. [Internet]. 2008. 2010. 02. 8. Feb 5. X-7.
151 Beaver BL, Moore VL, Peclet M, et al. Characteristics of pediatric firearm fatalities. J Pediatr Surg. 01. 1990;25(1):97-9. discussion 99–100. X-1, X-3. [pmid: 2299552].
152 Beck RJ, Franke DL. Rehabilitation of victims of natural disasters. Journal of Rehabilitation. 1996;62(4):28-32. X-2.
153 Bedard M, Felteau M, Mazmanian D, et al. Pilot evaluation of a mindfulness-based intervention to improve quality of life among individuals who sustained traumatic brain injuries. Disabil Rehabil. 07. 8. 2003;25(13):722-31. X-5. [pmid: 12791557].
154 Bell KR, Sandel ME. Brain injury rehabilitation 4 Postacute rehabilitation and community integration. Archives of Physical Medicine & Rehabilitation. 03. 1998;79(3 Suppl 1):S21-5. S31. 6. X-2.
155 Bell RB, Dierks EJ, Homer L, et al. Management of cerebrospinal fluid leak associated with craniomaxillofacial trauma. J Oral Maxillofac Surg. 06. 2004;62(6):676-84. X-1. [pmid: 15170277].
156 Belmont A, Agar N, Azouvi P. Subjective fatigue, mental effort, and attention deficits after severe traumatic brain injury. Neurorehabil Neural Repair. 11. 2009;23(9):939-44. X-1, X-5. [pmid: 19574545].
157 Belmont A, Agar N, Hugeron C, et al. Fatigue and traumatic brain injury. Annales de Readaptation et de. Medecine Physique. 2006;49(6):370-374. X-1, X-2.
158 Benesch K. Legal issues in determining competence to make treatment decisions. New Dir Ment Health Serv. Spring. 1989;(41):97-105. X-1.
159 Beresford TP, Arciniegas D, Clapp L, et al. Reduction of affective lability and alcohol use following traumatic brain injury: a clinical pilot study of anti-convulsant medications. Brain Inj. 04. 2005;19(4):309-13. X-2, X-5. [pmid: 15832875].
160 Berger JC. Traffic accidents, facial injuries, and psychiatry. Clin Plast Surg. 01. 1975;2(1):3-10. X-1, X-2. [pmid: 1116323].
161 Bergsneider M, Hovda DA, Lee SM, et al. Dissociation of cerebral glucose metabolism and level of consciousness during the period of metabolic depression following human traumatic brain injury. J Neurotrauma. 05. 2000;17(5):389-401. X-1. [pmid: 10833058].
162 Beric A, Kelly PJ, Rezai A, et al. Complications of deep brain stimulation surgery. Stereotact Funct Neurosurg. 2001;77(1–4):73-8. X-1. [pmid: 12378060].
163 Berkovic SF. Epilepsy: insights into causes and treatment dilemmas. The Lancet Neurology. 2010;9(1):9-11. X-1, X-2.
164 Bernick C, Stern LZ. Neurologic complaints in the elderly. The challenge of diagnosis. Postgrad Med. 06. 1985;77(8):124-9. 132. 3. X-1. [pmid: 4001035].
165 Berry KK. Effectively using the psychologic evaluation with children. Some guidelines to assist the pediatrician on making referrals for psychologic evaluation. Clin Pediatr (Phila). 03. 1973;12(3):174-7. X-1. [pmid: 4121793].
166 Berthier ML, Kulisevsky J, Fernandez Benitez JA, et al. Reactivation of posttraumatic stress disorder after minor head injury. Depress Anxiety. 1998;8(1):43-7. X-5. [pmid: 9750980].
167 Berthier ML, Kulisevsky JJ, Gironell A, et al. Obsessivecompulsive disorder and traumatic brain injury: behavioral, cognitive, and neuroimaging findings. Neuropsychiatry Neuropsychol Behav Neurol. 01. 2001;14(1):23-31. X-5. [pmid: 11234906].
168 Berthier ML, Posada A, Puentes C. Dissociative flashbacks after right frontal injury in a vietnam veteran with combat-related posttraumatic stress disorder. J Neuropsychiatry Clin Neurosci. Winter. 2001;13(1):101-5. X-1, X-5. [pmid: 11207336].
169 Bessell AL, Watkins ER, Williams WH. Depressive rumination reduces specificity of autobiographical memory recall in acquired brain injury. J Int Neuropsychol Soc. 01. 2008;14(1):63-70. X-1, X-5. [pmid: 18078532].
170 Bessette RF, Peterson LG. Fluoxetine and organic mood syndrome. Psychosomatics. 1992;33(2):224-226. X-1, X-2, X-5. [pmid: 1557490].
171 Betz P, Peschel O, Stiefel D, et al. Frequency of blood spatters on the shooting hand and of conjunctival petechiae following suicidal gunshots wounds to the head. Forensic Sci Int. 11. 30. 1995;76(1):47-53. X-1. [pmid: 8591835].
172 Bhat BV, Kumar A, Oumachigui A. Bone injuries during delivery. Indian J Pediatr. 07–08. 1994;61(4):401-5. X-1, X-3. [pmid: 8002070].
173 Bhatti SH, Ahmed I, Qureshi NA, et al. Head trauma due to earthquake October, 2005 - experience of 300 cases at the Combined Military Hospital Rawalpindi. J Coll Physicians Surg Pak. 01. 2008;18(1):22-6. X-1. [pmid: 18452663].
174 Bierley RA, Drake AI, Ahmed S, et al. Biased responding: a case series demonstrating a relationship between somatic symptoms and impaired recognition memory performance for traumatic brain injured individuals. Brain Inj. 08. 2001;15(8):697-714. X-5. [pmid: 11485610].
175 Binder LS, Leake LA. Chloral hydrate for emergent pediatric procedural sedation: a new look at an old drug. Am J Emerg Med. 11. 1991;9(6):530-4. X-1, X-3. [pmid: 1930390].
176 Bingham RM, Procaccio F, Prior PF, et al. Cerebral electrical activity influences the effects of etomidate on cerebral perfusion pressure in traumatic coma. Br J Anaesth. 09. 1985;57(9):843-8. X-1. [pmid: 4027099].
177 Birrell RG, Birrell JH. The maltreatment syndrome in children: a hospital survey. Med J Aust. 12. 7. 1968;2(23):1023-9. X-1. [pmid: 5727856].
178 Bishop DS, Miller IW. Traumatic brain injury: empirical family assessment techniques. Journal of Head Trauma Rehabilitation. 12. 1988;3(4):16-30. X-2.
179 Bisson JI, Shepherd JP, Dhutia M. Psychological sequelae of facial trauma. J Trauma. 09. 1997;43(3):496-500. X-1, X-5. [pmid: 9314314].
180 Bjornstig U, Bjornstig J, Eriksson A. Passenger car collision fatalities--with special emphasis on collisions with heavy vehicles. Accid Anal Prev. 01. 2008;40(1):158-66. X-1. [pmid: 18215544].
181 Black AW. Unilateral brain lesions and MMPI performance: A preliminary study. Perceptual and Motor Skills. 02. 1975;40(1):87-93. X-5. [pmid: 235117].
182 Black DW. Mental changes resulting from subdural haematoma. Br J Psychiatry. 08. 1984;145:200-3. X-1. [pmid: 6466919].
183 Black FW. The utility of the Shipley-Hartford as a predictor of WAIS full-scale IQ for patients with traumatic head injuries. J Clin Psychol. 04. 1974;30(2):168-70. X-1, X-5.
184 Blake H, Batson M. Exercise intervention in brain injury: a pilot randomized study of Tai Chi Qigong. Clin Rehabil. 07. 2009;23(7):589-98. X-1. [pmid: 19237436].
185 Blanco Pampin J, Morte Tamayo N, Hinojal Fonseca R, et al. Delayed presentation of carotid dissection, cerebral ischemia, and infarction following blunt trauma: Two cases. Journal of Clinical Forensic Medicine. 2002;9(3):136-140. X-1, X-2, X-5. [pmid: 15274948].
186 Blicher JU, Nielsen JF. Does long-term outcome after intensive inpatient rehabilitation of acquired brain injury depend on etiology. NeuroRehabilitation. 2008;23(2):175-83. X-1. [pmid: 18525139].
187 Bloom DR, Levin HS, Ewing-Cobbs L, et al. Lifetime and novel psychiatric disorders after pediatric traumatic brain injury. J Am Acad Child Adolesc Psychiatry. 05. 2001;40(5):572-9. X-3, X-5. [pmid: 11349702].
188 Blossey HC, Wander HE, Koebberling J, et al. Pharmacokinetic and pharmacodynamic basis for the treatment of metastatic breast cancer with high-dose medroxyprogesterone acetate. Cancer. 09. 15. 1984;54(6 Suppl):1208-15. X-1. [pmid: 6088020].
189 Blumenthal R. Suicidal gunshot wounds to the head: a retrospective review of 406 cases. Am J Forensic Med Pathol. 12. 2007;28(4):288-91. X-1. [pmid: 18043013].
190 Blumer D, Migeon C. Hormone and hormonal agents in the treatment of aggression. J Nerv Ment Dis. 02. 1975;160(2–1):127-37. X-1. [pmid: 123269].
191 Boake C, Freeland JC, Ringholz GM, et al. Awareness of memory loss after severe closed-head injury. Brain Inj. 04. 1995;9(3):273-83. X-5. [pmid: 7606238].
192 Bogner J, Corrigan JD. Reliability and predictive validity of the Ohio State University. TBI identification method with prisoners. J Head Trauma Rehabil. 07–08. 2009;24(4):279-91. X-1. [pmid: 19625867].
193 Bohnen N, Jolles J, Twijnstra A, et al. Coping styles, cortisol reactivity, and performance in a vigilance task of patients with persistent postconcussive symptoms after a mild head injury. Int J Neurosci. 05–06. 1992;64(1–4):97-105. X-5. [pmid: 1342053].
194 Bohnen NI, Jolles J, Twijnstra A, et al. Late neurobehavioural symptoms after mild head injury. Brain Inj. 01. 1995;9(1):27-33. X-5. [pmid: 7874093].
195 Bohnert M, Schmidt U, Perdekamp MG, et al. Diagnosis of a captive-bolt injury in a skull extremely destroyed by fire. Forensic Sci Int. 07. 17. 2002;127(3):192-7. X-1, X-5. [pmid: 12175948].
196 Boiko AN, Batysheva TT, Matvievskaya OV, et al. Characteristics of the formation of chronic fatigue syndrome and approaches to its treatment in young patients with focal brain damage. Neurosci Behav Physiol. 03. 2007;37(3):221-8. X-1, X-5. [pmid: 17294097].
197 Boivin DB, James FO, Santo JB, et al. Non-24-hour sleep-wake syndrome following a car accident. Neurology. 2003;60(11):1841-1843. X-1, X-2, X-5. [pmid: 12796546].
198 Bombardier CH, Bell KR, Temkin NR, et al. The efficacy of a scheduled telephone intervention for ameliorating depressive symptoms during the first year after traumatic brain injury. J Head Trauma Rehabil. 07–08. 2009;24(4):230-8. X-1. [pmid: 19625862].
199 Bonadio WA, Smith DS, Hillman S. Clinical indicators of intracranial lesion on computed tomographic scan in children with parietal skull fracture. Am J Dis Child. 02. 1989;143(2):194-6. X-1, X-3. [pmid: 2916490].
200 Bond MR. Assessment of the psychosocial outcome after severe head injury. Ciba Found Symp. 1975;(34):141-57. X-1, X-4. [pmid: 1045990].
201 Boone KB. Fixed belief in cognitive dysfunction despite normal neuropsychological scores: Neurocognitive hypochondriasis. Clinical Neuropsychologist. 2009;23(6):1016-1036. X-1. [pmid: 18923966].
202 Boosalis MG, Ott L, Levine AS, et al. Relationship of visceral proteins to nutritional status in chronic and acute stress. Crit Care Med. 08. 1989;17(8):741-7. X-1. [pmid: 2502363].
203 Bootes K, Chapparo CJ. Cognitive and behavioural assessment of people with traumatic brain injury in the work place: occupational therapists’ perceptions. Work. 2002;19(3):255-68. X-1, X-5. [pmid: 12547970].
204 Borg J, Holm L, Peloso PM, et al. Non-surgical intervention and cost for mild traumatic brain injury: Results of the WHO Collaborating Centre Task Force on Mild Traumatic Brain Injury. Journal of Rehabilitation Medicine, Supplement. Issue. 2004;43:76-83. X-1, X-2.
205 Borromei A, Cavrini G, Guerra L, et al. Elective neurotraumatology and therapeutic strategies in early post-trauma. Funct Neurol. 03–04. 1997;12(2):89-99. X-6. [pmid: 9238343].
206 Bostrom L, Nilsson B. A review of serious injury and death from gunshot wounds in Sweden: 1987 to 1994. Eur J Surg. 10. 1999;165(10):930-6. X-1. [pmid: 10574099].
207 Bouwens SF, van Heugten CM, Verhey FR. The practical use of goal attainment scaling for people with acquired brain injury who receive cognitive rehabilitation. Clin Rehabil. 04. 2009;23(4):310-20. X-5. [pmid: 19179354].
208 Bowen A, Chamberlain MA, Tennant A, et al. The persistence of mood disorders following traumatic brain injury: a 1 year follow-up. Brain Inj. 07. 1999;13(7):547-53. X-1. [pmid: 10462151].
209 Bowen A, Neumann V, Conner M, et al. Mood disorders following traumatic brain injury: identifying the extent of the problem and the people at risk. Brain Inj. 03. 1998;12(3):177-90. X-6. [pmid: 9547948].
210 Boyer RS, Rodin EA, Grey TC, et al. The skull and cervical spine radiographs of Tutankhamen: a critical appraisal. AJNR Am J Neuroradiol. 06–07. 2003;24(6):1142-7. X-1, X-5. [pmid: 12812942].
211 Boyle GJ, Haines S. Severe traumatic brain injury: some effects on family caregivers. Psychol Rep. 04. 2002;90(2):415-25. X-1, X-2, X-5. [pmid: 12061578].
212 Boyle RJ, Le C, Balloch A, et al. The clinical syndrome of specific antibody deficiency in children. Clin Exp Immunol. 12. 2006;146(3):486-92. X-1. [pmid: 17100769].
213 Braakman R. Survey and follow-up of 225 consecutive patients with a depressed skull fracture. J Neurol Neurosurg Psychiatry. 02. 1971;34(1):106. X-1, X-2, X-4. [pmid: 4994608].
214 Braakman R. Depressed skull fracture: data, treatment, and follow-up in 225 consecutive cases. J Neurol Neurosurg Psychiatry. 06. 1972;35(3):395-402. X-1, X-4. [pmid: 5035313].
215 Bradbury CL, Christensen BK, Lau MA, et al. The efficacy of cognitive behavior therapy in the treatment of emotional distress after acquired brain injury. Arch Phys Med Rehabil. 12. 2008;89(12 Suppl):S61-8. X-5. [pmid: 19081443].
216 Bradley L, Tawfiq N. The physical and psychological effects of torture in Kurds seeking asylum in the United Kingdom. Torture. 2006;16(1):41-7. X-1, X-5. [pmid: 17460346].
217 Braine ME. The role of the hypothalamus, part 3: a key to the control of emotions and behaviour. British Journal of Neuroscience Nursing. 04. 2009;5(4):157-64. X-1, X-2.
218 Branca B, Giordani B, Lutz T, et al. Self-report of cognition and objective test performance in posttraumatic headache. Headache. 05. 1996;36(5):300-6. X-1. [pmid: 8682671].
219 Braun CM, Baribeau JM, Ethier M, et al. Processing of pragmatic and facial affective information by patients with closed-head injuries. Brain Inj. 01–03. 1989;3(1):5-17. X-1, X-5. [pmid: 2924039].
220 Braun CM, Lussier F, Baribeau JM, et al. Does severe traumatic closed head injury impair sense of humour. Brain Inj. 10–12. 1989;3(4):345-54. X-1, X-5. [pmid: 2819315].
221 Brenner LA, Carlson NE, Harrison-Felix C, et al. Self-inflicted traumatic brain injury: Characteristics and outcomes. Brain Injury. 2009;23(13–14):991-998. X-1, X-5. [pmid: 19891537].
222 Brenner LA, Dise-Lewis JE, Bartles SK, et al. The long-term impact and rehabilitation of pediatric traumatic brain injury: A 50-year follow-up case study. Journal of Head Trauma Rehabilitation. 2007;22(1):56-64. X-2, X-3, X-5. [pmid: 17235232].
223 Brenner LA, Homaifar BY, Adler LE, et al. Suicidality and veterans with a history of traumatic brain injury: precipitating events, protective factors, and prevention strategies. Rehabilitation Psychology. 11. 2009;54(4):390-397. X-5. [pmid: 19929120].
224 Brenner LA, Ladley-O’Brien SE, Harwood JEF, et al. An exploratory study of neuroimaging, neurologic, and neuropsychological findings in veterans with traumatic brain injury and/or posttraumatic stress disorder. Military Medicine. 04. 2009;174(4):347-352. X-1. [pmid: 19485102].
225 Brewer-Smyth K. Neurologic and neuroendocrine correlates of violent criminal behavior of female inmates. University of Pennsylvania. 2001:142. X-7.
226 Brewer-Smyth K, Burgess AW. Childhood sexual abuse by a family member, salivary cortisol, and homicidal behavior of female prison inmates. Nurs Res. 05–06. 2008;57(3):166-74. X-1. [pmid: 18496102].
227 Brewer-Smyth K, Burgess AW, Shults J. Physical and sexual abuse, salivary cortisol, and neurologic correlates of violent criminal behavior in female prison inmates. Biol Psychiatry. 01. 1. 2004;55(1):21-31. X-1, X-5. [pmid: 14706421].
228 Brickley MR, Shepherd JP. The relationship between alcohol intoxication, injury severity and Glasgow Coma Score in assault patients. Injury. 06. 1995;26(5):311-4. X-1, X-5. [pmid: 7649645].
229 Brissos S, Dias VV. Bipolar disorder after traumatic brain injury. International Journal of Psychiatry in Clinical Practice. 12. 2005;9(4):292-295. X-5.
230 Brody DL, Magnoni S, Schwetye KE, et al. Amyloid-beta dynamics correlate with neurological status in the injured human brain. Science. 08. 29. 2008;321(5893):1221-4. X-1. [pmid: 18755980].
231 Brooks DN. What is a good re-entry programme? What are the key-question?--J. Douglas Miller Memorial Lecture. Acta Neurochir Suppl. 2002;79:59-60. X-1. [pmid: 11974989].
232 Brown M, Dijkers MP, Gordon WA, et al. Participation objective, participation subjective: a measure of participation combining outsider and insider perspectives. J Head Trauma Rehabil. 11–12. 2004;19(6):459-81. X-1. [pmid: 15602309].
233 Brown PN. Guilt by physiology: the constitutionality of tests to determine predisposition to violent behavior. South Calif Law Rev. 11. 1974;48(2):489-570. X-1. [pmid: 11662163].
234 Brownell HH, Carroll JJ, Rehak A, et al. The use of pronoun anaphora and speaker mood in the interpretation of conversational utterances by right hemisphere brain-damaged patients. Brain Lang. 07. 1992;43(1):121-47. X-1, X-5. [pmid: 1643507].
235 Bruce-Chwatt RM. Air gun wounding and current UK laws controlling air weapons. Journal of Forensic and Legal Medicine. 2010;17(3):123-126. X-1, X-2. [pmid: 20211450].
236 Bruckner FE, Randle AP. Return to work after severe head injuries. Rheumatol Phys Med. 08. 1972;11(7):344-8. X-1. [pmid: 5069951].
237 Bryant RA. Disentangling mild traumatic brain injury and stress reactions. N Engl J Med. 01. 31. 2008;358(5):525-7. X-1, X-2, X-4, X-5. [pmid: 18234757].
238 Bryant RA. Disentangling mild traumatic brain injury and stress reactions [editorial]. New England Journal of Medicine. 01. 31. 2008;358(5):525-527. X-2. [pmid: 18234757].
239 Bryant RA, Creamer M, O’Donnell M, et al. A study of the protective function of acute morphine administration on subsequent posttraumatic stress disorder. Biol Psychiatry. 03. 1. 2009;65(5):438-40. X-1. [pmid: 19058787].
240 Bryant RA, Marosszeky JE, Crooks J, et al. Interaction of posttraumatic stress disorder and chronic pain following traumatic brain injury. J Head Trauma Rehabil. 12. 1999;14(6):588-94. X-1. [pmid: 10671704].
241 Bryant RA, Moulds M, Guthrie R, et al. Treating acute stress disorder following mild traumatic brain injury. Am J Psychiatry. 03. 2003;160(3):585-7. X-1, X-5. [pmid: 12611847].
242 Buchanan KM, Elias LJ. Personality & behaviour changes following spinal cord injury: self perceptions--partner’s perceptions. Axone. 12. 1999;21(2):36-9. X-1, X-5. [pmid: 10732522].
243 Buchanan RJ, Wang S, Huang C. Profiles of nursing home residents with traumatic brain injury using the Minimum Data Set. Brain Inj. 06. 2003;17(6):507-23. X-1. [pmid: 12745706].
244 Bulinski L. Social reintegration of TBI patients: a solution to provide long-term support. Med Sci Monit. 01. 2010;16(1):PH14-23. X-1, X-5. [pmid: 20037500].
245 Bulut M, Koksal O, Dogan S, et al. Tau protein as a serum marker of brain damage in mild traumatic brain injury: preliminary results. Adv Ther. 01–02. 2006;23(1):12-22. X-1, X-4. [pmid: 16644603].
246 Bum SJ, Chang HL, Jee WC. Secondary hypomania following left temporopolar and bilateral orbitofrontal damage. Clinical Psychopharmacology & Neuroscience. 2007;5(1):38-41. X-5.
247 Burg JS. Psychiatric treatment outcome following traumatic brain injury. Dissertation Abstracts International: Section B: The Sciences and Engineering. 1997;57(12-B). X-7.
248 Burg JS, Williams R, Burright RG, et al. Psychiatric treatment outcome following traumatic brain injury. Brain Inj. 06. 2000;14(6):513-33. X-1, X-5. [pmid: 10887886].
249 Burgess J. Symptom characteristics in TMD patients reporting blunt trauma and/or whiplash injury. J Craniomandib Disord. Fall. 1991;5(4):251-7. X-1, X-5. [pmid: 1814967].
250 Burke JM, Imhoff CL, Kerrigan JM. MMPI correlates among post-acute TBI patients. Brain Inj. 07–09. 1990;4(3):223-31. X-1. [pmid: 2390648].
251 Burke JM, Smith SA, Imhoff CL. The response styles of post-acute traumatic braininjured patients on the MMPI. Brain Inj. 01–03. 1989;3(1):35-40. X-5. [pmid: 2924037].
252 Burns S, Kappenberg R, McKenna A, et al. Brain injury: personality, psychopathology and neuropsychology. Brain Inj. 07. 1994;8(5):413-27. X-1. [pmid: 7951204].
253 Burton LA, Volpe BT. Depression after head injury: Do physical and cognitive sequelae have similar impact. Journal of Neurologic Rehabilitation. 1994;8(2):63-67. X-5.
254 Bush BA, Novack TA, Schneider JJ, et al. Depression Following Traumatic Brain Injury: The Validity of the CES-D as a Brief Screening Device. Journal of Clinical Psychology in Medical Settings. 09. 2004;11(3):195-201. X-1, X-2.
255 Bushnik T, Englander J, Wright J. The experience of fatigue in the first 2 years after moderate-to-severe traumatic brain injury: a preliminary report. J Head Trauma Rehabil. 01–02. 2008;23(1):17-24. X-5. [pmid: 18219231].
256 Buzzi MG, Bivona U, Matteis M, et al. Cognitive and psychological patterns in posttraumatic headache following severe traumatic brain injury. Cephalalgia. [Meeting]. 09. 2003;23(7):672. X-7.
257 Byrnes DP. Management of depressed fractures of the skull. J Ir Med Assoc. 06. 29. 1974;67(12):337-42. X-1, X-4. [pmid: 4209244].
258 Cabraal SA, Abeysuriya SC. The management of compound depressed fractures of the skull. Ceylon Med J. 09. 1969;14(3):105-15. X-1. [pmid: 5370219].
259 Cahill CM, Murphy KC. Migraine and depersonalization disorder. Cephalalgia. 2004;24(8):686-687. X-1. [pmid: 15265059].
260 Cairns V, Faltermaier T, Wittchen HU, et al. Some problems concerning the reliability and structure of the scales in the inpatient multidimensional psychiatric scale (IMPS). Arch Psychiatr Nervenkr. 1982;232(5):395-406. X-1. [pmid: 7171298].
261 Calvert S, Miller HE, Curran A, et al. The King’s Outcome Scale for Childhood Head Injury and injury severity and outcome measures in children with traumatic brain injury. Dev Med Child Neurol. 06. 2008;50(6):426-31. X-3. [pmid: 18422680].
262 Campbell D, Marion K, Henry J, et al. Book marks. Canadian Journal of Occupational Therapy. 04. 2006;73(2):124-7. X-2.
263 Cander B, Kalkan E, Girisgin S, et al. Emergency operation indications in emergency medicine clinic (model of emergency medicine in Turkey). Adv Ther. 03–04. 2006;23(2):359-63. X-1. [pmid: 16751168].
264 Cannon TC, Jordan FB, Vogel JS, et al. Child homicide in Oklahoma: a continuing public health problem. J Okla State Med Assoc. 11. 1998;91(8):449-51. X-1, X-3. [pmid: 9828528].
265 Cantagallo A, Dimarco F. Prevalence of neuropsychiatric disorders in traumatic brain injury patients. Europa Medicophysica. 2002;38(4):167-78. X-1.
266 Cantor J, Ashman T, Brown M, et al. Self-discrepancy theory & post-TBI affective disorders: a pilot study. Neurorehabilitation & Neural Repair. 2005;19(4):392-3. X-1, X-5.
267 Cantor JB, Ashman T, Gordon W, et al. Fatigue after traumatic brain injury and its impact on participation and quality of life. J Head Trauma Rehabil. 01–02. 2008;23(1):41-51. X-1. [pmid: 18219234].
268 Cantor JB, Ashman TA, Schwartz ME, et al. The role of self-discrepancy theory in understanding post-traumatic brain injury affective disorders: a pilot study. J Head Trauma Rehabil. 11–12. 2005;20(6):527-43. X-5. [pmid: 16304489].
269 Canturk G, Canturk N, Odabasi AB, et al. Autopsy findings of suicidal deaths committed by firearms in Ankara, Turkey. Med Sci Law. 07. 2009;49(3):207-12. X-1. [pmid: 19787993].
270 Caplan B, Gibson CJ, Weiss R. Stressful sequelae of disabling illness. Int Rehabil Med. 1984;6(2):58-62. X-1, X-5. [pmid: 6235199].
271 Carey JC, Wade SL, Wolfe CR. Lessons learned: the effect of prior technology use on Web-based interventions. Cyberpsychol Behav. 04. 2008;11(2):188-95. X-3. [pmid: 18422412].
272 Carlson KF, Nelson DB, Orazem RJ, et al. Psychiatric diagnoses among Iraq and Afghanistan war veterans screened for deployment-related traumatic brain injury. Journal of Traumatic Stress. 02. 2010;23(1):17-24. X-1. [pmid: 20127725].
273 Carnevale GJ, Anselmi V, Johnston MV, et al. A natural setting behavior management program for persons with acquired brain injury: a randomized controlled trial. Arch Phys Med Rehabil. 10. 2006;87(10):1289-97. X-1, X-5. [pmid: 17023236].
274 Carswell K, Maughan B, Davis H, et al. The psychosocial needs of young offenders and adolescents from an inner city area. J Adolesc. 08. 2004;27(4):415-28. X-1, X-4. [pmid: 15288751].
275 Carter BG, Butt W, Taylor A. Bilaterally absent pupillary responses: Not always a bad sign. Anaesthesia & Intensive Care. 2007;35(6):984-987. X-1, X-3. [pmid: 18084996].
276 Carter TG, Bagheri S, Dierks EJ. Towel clip reduction of the depressed zygomatic arch fracture. J Oral Maxillofac Surg. 08. 2005;63(8):1244-6. X-1. [pmid: 16094600].
277 Cassidy JW. Fluoxetine: A new serotonergically active antidepressant. Journal of Head Trauma Rehabilitation. Special Issue: Visual system dysfunction. 06. 1989;4(2):67-69. X-5.
278 Castriotta RJ, Atanasov S, Wilde MC, et al. Treatment of sleep disorders after traumatic brain injury. J Clin Sleep Med. 04. 15. 2009;5(2):137-44. X-1. [pmid: 19968047].
279 Castriotta RJ, Wilde MC, Lai JM, et al. Prevalence and consequences of sleep disorders in traumatic brain injury. J Clin Sleep Med. 06. 15. 2007;3(4):349-56. X-1. [pmid: 17694722].
280 Cavicchi LS, Pfeiffer D. Implementation planning for a neuro-behavioral unit in a public health hospital. J Health Hum Resour Adm. Fall. 1990;13(2):219-27. X-1. [pmid: 10109573].
281 Ceviker N, Baykaner K, Keskil S, et al. Moderate head injuries in children as compared to other age groups, including the cases who had talked and deteriorated. Acta Neurochir (Wien). 1995;133(3–4):116-21. X-1, X-4, X-5. [pmid: 8748753].
282 Chadwick O. Psychological sequelae of head injury in children. Dev Med Child Neurol. 02. 1985;27(1):72-5. X-1. [pmid: 3979675].
283 Chagas Silva M, Gaunekar G, Patel V, et al. The prevalence and correlates of hazardous drinking in industrial workers: a study from Goa, India. Alcohol Alcohol. 01–02. 2003;38(1):79-83. X-1. [pmid: 12554613].
284 Chahine LM, Chemali Z. Du rire aux larmes: pathological laughing and crying in patients with traumatic brain injury and treatment with lamotrigine. Epilepsy Behav. 05. 2006;8(3):610-5. X-1, X-3, X-5. [pmid: 16504590].
285 Chaiklin H, McCauley SR, Ruggero C, et al. Book reviews. Journal of Nervous & Mental Disease. 06. 2007;195(6):546-50. X-2.
286 Chalton LD, McMillan TM. Can ‘partial’ PTSD explain differences in diagnosis of PTSD by questionnaire self-report and interview after head injury. Brain Inj. 02. 2009;23(2):77-82. X-5. [pmid: 19191086].
287 Chamnanvanakij S, Rollins N, Perlman JM. Subdural hematoma in term infants. Pediatr Neurol. 04. 2002;26(4):301-4. X-1, X-3. [pmid: 11992759].
288 Chan F, Lanctot KL, Feinstein A, et al. The serotonin transporter polymorphisms and major depression following traumatic brain injury. Brain Inj. 06. 2008;22(6):471-9. X-1. [pmid: 18465388].
289 Chan J, Parmenter T, Stancliffe R. The impact of traumatic brain injury on the mental health outcomes of individuals and their family carers. AeJAMH (Australian e-Journal for the Advancement of Mental Health). 08. 2009;8(2):1-10. X-2.
290 Chan RC, Manly T. The application of “dysexecutive syndrome” measures across cultures: performance and checklist assessment in neurologically healthy and traumatically brain-injured Hong Kong Chinese volunteers. J Int Neuropsychol Soc. 09. 2002;8(6):771-80. X-1, X-5. [pmid: 12240741].
291 Chandler JD, Gerndt J. Cognitive screening tests for organic mental disorders in psychiatric inpatients: A hopeless task?. Journal of Nervous and Mental Disease. 11. 1988;176(11):675-681. X-1. [pmid: 3183652].
292 Chang YC, Tsai JC, Tseng FY. Neuropsychiatric disturbances and hypopituitarism after traumatic brain injury in an elderly man. Journal of the Formosan Medical Association. 2006;105(2):172-176. X-2, X-5. [pmid: 16477340].
293 Chaput G, Giguere JF, Chauny JM, et al. Relationship among subjective sleep complaints, headaches, and mood alterations following a mild traumatic brain injury. Sleep Med. 08. 2009;10(7):713-6. X-6. [pmid: 19147402].
294 Chaytor N, Temkin N, Machamer J, et al. The ecological validity of neuropsychological assessment and the role of depressive symptoms in moderate to severe traumatic brain injury. J Int Neuropsychol Soc. 05. 2007;13(3):377-85. X-1, X-4. [pmid: 17445285].
295 Chen AJ, D’Esposito M. Traumatic brain injury: from bench to beside to society. Neuron. 04. 15. 2010;66(1):11-4. X-1, X-2. [pmid: 20399725].
296 Chen JK, Johnston KM, Petrides M, et al. Neural substrates of symptoms of depression following concussion in male athletes with persisting postconcussion symptoms. Arch Gen Psychiatry. 01. 2008;65(1):81-9. X-5. [pmid: 18180432].
297 Cheung G. Posttraumatic Kleine-Levin syndrome. General Hospital Psychiatry. 2006;28(5):443-445. X-1, X-2, X-5. [pmid: 16950384].
298 Chibnall JT, Duckro PN. Post-traumatic stress disorder in chronic post-traumatic headache patients. Headache. 06. 1994;34(6):357-61. X-1, X-5. [pmid: 7928315].
299 Chibnall JT, Duckro PN, Greenberg MS. Evidence for construct validity of the TMJ scale in a sample of chronic post-traumatic headache patients. Cranio. 07. 1994;12(3):184-9. X-1, X-5. [pmid: 7813031].
300 Chow TW, Pollock BG, Milgram NW. Potential cognitive enhancing and disease modification effects of SSRIs for Alzheimer’s disease. Neuropsychiatric Disease and Treatment. 2007;3(5):627-636. X-1, X-2, X-5. [pmid: 19300592].
301 Christofides J, Bridel M, Egerton M, et al. Blood 5-hydroxytryptamine, 5-hydroxyindoleacetic acid and melatonin levels in patients with either Huntington’s disease or chronic brain injury. J Neurochem. 05. 2006;97(4):1078-88. X-1. [pmid: 16573644].
302 Chua HC, Tan CB, Tjia H. Aberrant regeneration of the third nerve. Singapore Med J. 09. 2000;41(9):458-9. X-1, X-5. [pmid: 11193120].
303 Cicerone KD, Kalmar K. Does premorbid depression influence post-concussive symptoms and neuropsychological functioning. Brain Inj. 09. 1997;11(9):643-8. X-5. [pmid: 9376832].
304 Claassen J, Peery S, Kreiter KT, et al. Predictors and clinical impact of epilepsy after subarachnoid hemorrhage. Neurology. 01. 28. 2003;60(2):208-14. X-1, X-5. [pmid: 12552032].
305 Clarke A, Rumsey N, Collin JR, et al. Psychosocial distress associated with disfiguring eye conditions. Eye. 01. 2003;17(1):35-40. X-1. [pmid: 12579168].
306 Clarke P. Complications of depressed skull fracture. Lancet. 11. 30. 1968;2(7579):1192. X-1, X-2, X-4, X-5. [pmid: 4176976].
307 Clemens B. Abnormal quantitative EEG scores identify patients with complicated idiopathic generalised epilepsy. Seizure. 2004;13(6):366-374. X-1. [pmid: 15276139].
308 Coakham H. Computerized tomography of the brain. Practitioner. 03. 1978;220(1317):437-42. X-1. [pmid: 643789].
309 Cochrane J, Goering P, Durbin J, et al. Tertiary mental health services: II. Subpopulations and best practices for service delivery. Can J Psychiatry. 03. 2000;45(2):185-90. X-1, X-2, X-4, X-5. [pmid: 10742879].
310 Cock J, Fordham C, Cockburn J, et al. Who knows best? Awareness of divided attention difficulty in a neurological rehabilitation setting. Brain Inj. 07. 2003;17(7):561-74. X-1, X-5. [pmid: 12775269].
311 Coetzer R. A clinical pathway including psychotherapy approaches for managing emotional difficulties after acquired brain injury. CNS Spectrums. 11. 2009;14(11):632-638. X-1, X-2. [pmid: 20173688].
312 Coetzer R, Ruddle JA, Mulla F. The Brain Injury Grief Inventory: a follow-up study of emotional and functional outcome following traumatic brain injury. Journal of Cognitive Rehabilitation. 2006;24(2):7-11. X-5.
313 Cohen MA, Shakenovsky BN, Smith I. Low velocity hand-gun injuries of the maxillofacial region. J Maxillofac Surg. 02. 1986;14(1):26-33. X-1, X-5. [pmid: 3456410].
314 Colak A, Berker M, Ozcan OE. Occipital depression fractures in childhood. A report of 14 cases. Childs Nerv Syst. 04. 1991;7(2):103-5. X-1, X-3. [pmid: 1863927].
315 Colantonio A, Stamenova V, Abramowitz C, et al. Brain injury in a forensic psychiatry population. Brain Inj. 12. 2007;21(13–14):1353-60. X-1. [pmid: 18066937].
316 Colasanti A, Mauri MC, Paletta S, et al. Primary major depression versus post-traumatic brain injury major depression: psychopathological and neuropsychological differences. European Neuropsychopharmacology. [Meeting]. 08. 2008;18(Suppl 4):S582-S583. X-7.
317 Colclasure JB, Graham SS. Support of unstable nasal fractures with silicone rubber wedge splints. Arch Otolaryngol. 07. 1985;111(7):443-5. X-1. [pmid: 4015496].
318 Cole G. Autopsy findings in mental patients. S Afr Med J. 09. 17. 1977;52(13):534-6. X-1, X-5. [pmid: 918797].
319 Collicutt McGrath J, Linley PA. Post-traumatic growth in acquired brain injury: a preliminary small scale study. Brain Inj. 06. 2006;20(7):767-73. X-1, X-5. [pmid: 16809209].
320 Collins RC. Quality of life in individuals with traumatic brain injury: A needs-based approach to “Measuring what matters”. University of Minnesota. 2003:233. X-7.
321 Collins RC, Kennedy MC. Serving families who have served: Providing family therapy and support in interdisciplinary polytrauma rehabilitation. Journal of Clinical Psychology. 2008;64(8):993-1003. X-1, X-5. [pmid: 18553369].
322 Conners CK, Barta F Jr. Transfer of information from touch to vision in brain-injured and emotionally disturbed children. J Nerv Ment Dis. 08. 1967;145(2):138-41. X-1. [pmid: 6055773].
323 Conway GA, Moran KA, Mode NA. Scientific worker and licensed professional deaths in Alaska, 1990–2002. Int J Circumpolar Health. 2004;63(Suppl 2):353-6. X-1. [pmid: 15736683].
324 Cook N. Research round-up. British Journal of Neuroscience Nursing. 06. 2007;3(6):290-1. X-2.
325 Cooke BB, Keltner NL. Biological perspectives: traumatic brain injury-war related: part II. Perspect Psychiatr Care. 01. 2008;44(1):54-7. X-1, X-2, X-5. [pmid: 18177279].
326 Cooper J, Reynolds F, Bateman A. An evaluation of a fatigue management intervention for people with acquired brain injury: an exploratory study. British Journal of Occupational Therapy. 04. 2009;72(4):174-9. X-5.
327 Cooper JA, Ridley B. Response of intrathecal baclofen resistance to dose reduction. Neurology. 2006;67(8):1495-1496. X-1. [pmid: 17060585].
328 Cooper JK, Mungas D. Risk factor and behavioral differences between vascular and Alzheimer’s dementias: the pathway to end-stage disease. J Geriatr Psychiatry Neurol. 01–03. 1993;6(1):29-33. X-1. [pmid: 8422268].
329 Cooper-Evans S, Alderman N, Knight C, et al. Self-esteem as a predictor of psychological distress after severe acquired brain injury: an exploratory study. Neuropsychol Rehabil. 10–12. 2008;18(5–6):607-26. X-5. [pmid: 18609016].
330 Copeland AR. Suicide among nonwhites. The Metro Dade County experience, 1982–1986. Am J Forensic Med Pathol. 03. 1989;10(1):10-3. X-1. [pmid: 2929535].
331 Corkin S. Hidden-figures-test performance: lasting effects of unilateral penetrating head injury and transient effects of bilateral cingulotomy. Neuropsychologia. 1979;17(6):585-605. X-1. [pmid: 522973].
332 Correll RE, Brodginski SE, Rokosz SF. WAIS performance during the acute recovery stage following closed-head injury. Percept Mot Skills. 02. 1993;76(1):99-109. X-1. [pmid: 8451158].
333 Corrigan JD, Bogner JA, Mysiw WJ, et al. Life satisfaction after traumatic brain injury. J Head Trauma Rehabil. 12. 2001;16(6):543-55. X-4. [pmid: 11732970].
334 Corrigan JD, Deutschle JJ Jr. The presence and impact of traumatic brain injury among clients in treatment for co-occurring mental illness and substance abuse. Brain Inj. 03. 2008;22(3):223-31. X-1, X-5. [pmid: 18297594].
335 Coulson SE, O’Dwyer NJ, Adams RD, et al. Expression of emotion and quality of life after facial nerve paralysis. Otol Neurotol. 11. 2004;25(6):1014-9. X-1. [pmid: 15547436].
336 Covassin T, Schatz P, Swanik CB. Sex differences in neuropsychological function and post-concussion symptoms of concussed collegiate athletes. Neurosurgery. 08. 2007;61(2):345-50. discussion 350–1. X-1. [pmid: 17762747].
337 Crago BR, Gray MR, Nelson LA, et al. Psychological, neuropsychological, and electrocortical effects of mixed mold exposure. Arch Environ Health. 08. 2003;58(8):452-63. X-1. [pmid: 15259424].
338 Craig AR, Hancock KM, Dickson HG. Spinal cord injury: a search for determinants of depression two years after the event. Br J Clin Psychol. 05. 1994;33(Pt 2):221-30. X-1. [pmid: 8038741].
339 Crasilneck HB, Hall JA. The use of hypnosis in the rehabilitation of complicated vascular and post-traumatic neurological patients. Int J Clin Exp Hypn. 07. 1970;18(3):145-59. X-1, X-2, X-4, X-5. [pmid: 5484100].
340 Crawford JG. Alzheimer’s disease risk factors as related to cerebral blood flow. Med Hypotheses. 04. 1996;46(4):367-77. X-1, X-2. [pmid: 8733167].
341 Crawford JG. Alzheimer’s disease risk factors as related to cerebral blood flow: additional evidence. Med Hypotheses. 01. 1998;50(1):25-36. X-1. [pmid: 9488178].
342 Criden MR, Ellis FJ. Linear nondisplaced orbital fractures with muscle entrapment. J AAPO S. 04. 2007;11(2):142-7. X-1, X-3, X-5.
343 Crisp R. Depression and occupational disability in five diagnostic groups: A review of recent research. Disability and Rehabilitation: An International, Multidisciplinary Journal. 02. 2007;29(4):267-279. X-2, X-5.
344 Croker V, McDonald S. Recognition of emotion from facial expression following traumatic brain injury. Brain Inj. 09. 2005;19(10):787-99. X-1, X-5. [pmid: 16175839].
345 Cronholm B. Evaluation of mental disturbances after head injury. Scand J Rehabil Med. 1972;4(1):35-8. X-1, X-2, X-4, X-5. [pmid: 4220358].
346 Cronholm B, Hadell G, Lundgren KD. The pronostic value of vocational assessment. Scand J Rehabil Med. 1969;1(1):20-5. X-1. [pmid: 5406720].
347 Cross GM, Hirsch KA. Alcohol emergencies: how to recognize promptly, and what to do. Consultant. 05. 1997;37(5):1390-2. 1399. 400. 1402. X-1.
348 Cross RL. Biological mechanisms of depression in chronic disease. University of California. Los Angeles. 2007:79. X-1, X-2, X-5.
349 Crow S, Meller W, Christenson G, et al. Use of ECT after brain injury. Convulsive Therapy. 06. 1996;12(2):113-116. X-1, X-5. [pmid: 8744172].
350 Crowe SF, Ponsford J. The role of imagery in sexual arousal disturbances in the male traumatically brain injured individual. Brain Inj. 05. 1999;13(5):347-54. X-1, X-5. [pmid: 10367145].
351 Cummings JL. Progress. neurotherapeutics and neuropsychopharmacology 2008, Progress in Neurotherapeutics & Neuropsychopharmacology. 2008;3(1):1-11. X-1, X-2.
352 Cummings JL, Arciniegas DB, Brooks BR, et al. Defining and diagnosing involuntary emotional expression disorder. CNS Spectr. 06. 2006;11(6):1-7. X-1, X-2. [pmid: 16816786].
353 Cunningham DR, Merle KS, Genchur JA. Characteristics of a “nonspecific” ENG population. Ear Hear. 09–10. 1980;1(5):237-41. X-1. [pmid: 6968698].
354 Cupertino AP, Richter KP, Cox LS, et al. Smoking cessation pharmacotherapy preferences in rural primary care. Nicotine & Tobacco Research. 2008;10(2):301-307. X-1. [pmid: 18236294].
355 Curry DJ, Frim DM. Delayed repair of open depressed skull fracture. Pediatr Neurosurg. 12. 1999;31(6):294-7. X-1, X-3, X-5. [pmid: 10702728].
356 Cushman A, Rostan H, Marvin S, et al. Cerebral blood flow in gray and white matter of patients with depressed consciousness. Surg Forum. 1972;23(0):403-5. X-1. [pmid: 4671135].
357 Cutting S, Lauchheimer A, Barr W, et al. Adult-onset idiopathic generalized epilepsy: clinical and behavioral features. Epilepsia. 11. 2001;42(11):1395-8. X-1. [pmid: 11879340].
358 Daffner KR, Mesulam MM, Holcomb PJ, et al. Disruption of attention to novel events after frontal lobe injury in humans. J Neurol Neurosurg Psychiatry. 01. 2000;68(1):18-24. X-1, X-5. [pmid: 10601395].
359 Dalfen AK, Feinstein A. Head injury, dissociation and the Ganser syndrome. Brain Injury. 2000;14(12):1101-1105. X-1, X-2, X-5. [pmid: 11147582].
360 Dalton G. Transsphenoidal hypophysectomy for pituitary tumours. Proc R Soc Med. 09. 1974;67(9):885-9. X-1. [pmid: 4431803].
361 Daniel WF, Crovitz HF, Weiner RD. Neuropsychological aspects of disorientation. Cortex. 06. 1987;23(2):169-187. X-1, X-5. [pmid: 3608515].
362 Daniels JE, Wirth JB, Herrera DG, et al. Head banging on an inpatient psychiatric unit: a vicious circle. Harv Rev Psychiatry. 03–04. 2007;15(2):70-9. X-1. [pmid: 17454176].
363 Danis D, Halm K. The MMWR file. JEN: Journal of Emergency Nursing. 10. 1995;21(5):454-6. X-2.
364 Das S, Scott JS, Clark RA. Total body irradiation as an alternative to systemic chemotherapy in small-cell anaplastic lung cancer. Br J Clin Pract. 12. 1990;44(12):571-3. X-1, X-5. [pmid: 1966311].
365 Das-Gupta R, Turner-Stokes L. Traumatic brain injury. Disability and Rehabilitation. 2002;24(13):654-665. X-2. [pmid: 12296981].
366 David J, Cooks R. When the brain goes wrong: seven short films about brain disorders. Fanlight Productions. 1992. X-1, X-5.
367 David JS, Gelas-Dore B, Inaba K, et al. Are patients with self-inflicted injuries more likely to die. J Trauma. 06. 2007;62(6):1495-500. X-1. [pmid: 17563673].
368 Davidoff G, Roth E, Thomas P, et al. Depression among acute spinal cord injury patients: A study utilizing the Zung Self-Rating Depression Scale. Rehabilitation Psychology. Fal. 1990;35(3):171-180. X-1, X-5.
369 Davidson PN, Nehamkin S. Book review. American Journal of Electroneurodiagnostic Technology. 03. 2007;47(1):58-63. X-2.
370 Davis MC. Life review therapy as an intervention to manage depression and enhance life satisfaction in individuals with right hemisphere cerebral vascular accidents. Mississippi State University. 1997:88. X-1, X-5.
371 Davis RL, Mullen N, Makela M, et al. Cranial computed tomography scans in children after minimal head injury with loss of consciousness. Ann Emerg Med. 10. 1994;24(4):640-5. X-1, X-3. [pmid: 8092590].
372 Davis WS, Moreno JD. Decisional capacity and consent for research in older adults who are cognitively impaired. Ethics, Law & Aging Review. 2002;8:19-38. X-1, X-2, X-5.
373 Dawkins N, Cloherty ME, Gracey F, et al. The factor structure of the Hospital Anxiety and Depression Scale in acquired brain injury. Brain Inj. 11. 2006;20(12):1235-9. X-1. [pmid: 17132546].
374 Dawson DR, Cantanzaro AM, Firestone J, et al. Changes in coping style following traumatic brain injury and their relationship to productivity status. Brain Cogn. 03. 2006;60(2):214-6. X-1. [pmid: 16646128].
375 Dawson DR, Schwartz ML, Winocur G, et al. Return to productivity following traumatic brain injury: cognitive, psychological, physical, spiritual, and environmental correlates. Disabil Rehabil. 02. 28. 2007;29(4):301-13. X-1, X-5. [pmid: 17364780].
376 Dawson EL, Boyle NJ, Lee JP. Full-tendon nasal transposition of the vertical rectus muscles: a retrospective review. Strabismus. 07–09. 2007;15(3):133-6. X-1, X-3, X-5. [pmid: 17763249].
377 De Benedittis G, De Santis A. Chronic post-traumatic headache: clinical, psychopathological features and outcome determinants. J Neurosurg Sci. 07–09. 1983;27(3):177-86. X-1, X-3. [pmid: 6663350].
378 De Benedittis G, Ettorre G. Focal EEG in post-traumatic mild coma. Follow-up study on unoperated patients. J Neurosurg Sci. 01–03. 1974;18(1):20-5. X-1. [pmid: 4218259].
379 de Leon FC, Goodrich JT, Tutino M, et al. First published record of a neurosurgical procedure on the North American continent, Mexico City, by Pedro Arias de Benavides, 1561: Secretos de Chirurgia, Valladolid, Spain, 1567. Neurosurgery. 07. 2000;47(1):216-22. X-1, X-2, X-3, X-5. [pmid: 10917365].
380 de Paul Djientcheu V, Njamnshi AK, Ongolo-Zogo P, et al. Depressed skull fractures in children: Treatment using an obstetrical vacuum extractor. Pediatr Neurosurg. 2006;42(5):273-6. X-1, X-3, X-5. [pmid: 16902337].
381 De Santis A, Sganzerla E, Spagnoli D, et al. Risk factors for late posttraumatic epilepsy. Acta Neurochir Suppl (Wien). 1992;55:64-7. X-1, X-2, X-3. [pmid: 1414548].
382 Dealberto M-J, Marino J, Bourgon L. Homicidal ideation with intent during a manic episode triggered by antidepressant medication in a man with brain injury. Bipolar Disorders. 02. 2008;10(1):111-113. X-5. [pmid: 18199249].
383 Dean CE, Kuskowski MA, Caligiuri MP. Predictors of neuroleptic-induced dyskinesia and parkinsonism: The influence of measurement methods and definitions. Journal of Clinical Psychopharmacology. 2006;26(6):560-565. X-1. [pmid: 17110811].
384 Dean PM, Feldman DM, Morere D, et al. Clinical evaluation of the mini-mental state exam with culturally deaf senior citizens. Arch Clin Neuropsychol. 12. 2009;24(8):753-60. X-1. [pmid: 19861331].
385 Deb S, Lyons I, Koutzoukis C. Neuropsychiatric sequelae one year after a minor head injury. J Neurol Neurosurg Psychiatry. 12. 1998;65(6):899-902. X-1. [pmid: 9854967].
386 Dedek JF. Two moral cases: psychosurgery and behavior control; grossly malformed infants. Chic Stud. Spring. 1975;14(1):19-35. X-1. [pmid: 11662984].
387 Deehan SC, Grant IS. Haemodynamic changes in neurogenic pulmonary oedema: effect of dobutamine. Intensive Care Med. 07. 1996;22(7):672-6. X-1, X-5. [pmid: 8844233].
388 Deems DA, Doty RL, Settle RG, et al. Smell and taste disorders, a study of 750 patients from the University of Pennsylvania Smell and Taste Center. Arch Otolaryngol Head Neck Surg. 05. 1991;117(5):519-28. X-1. [pmid: 2021470].
389 Degeneffe CE, Lynch RT. Correlates of depression in adult siblings of persons with traumatic brain injury. Rehabilitation Counseling Bulletin. 2006;49(3):130-42. X-1.
390 DeJong RN. The neurologic aspects of dementia. Trans Am Neurol Assoc. 1973;98:109-13. X-1. [pmid: 4784914].
391 Del Monte P, Foppiani L, Ruelle A, et al. Clinically non-functioning pituitary macroadenomas in the elderly. Aging Clin Exp Res. 02. 2007;19(1):34-40. X-1, X-5. [pmid: 17332719].
392 Della Corte F, Giordano A, Pennisi MA, et al. Quantitative cerebral blood flow and metabolism determination in the first 48 hours after severe head injury with a new dynamic SPECT device. Acta Neurochir (Wien). 1997;139(7):636-41. discussion 641–2. X-1, X-5. [pmid: 9265957].
393 Dellacherie D, Ehrlé N, Samson S. Is the neutral condition relevant to study musical emotion in patients. Music Perception. 04. 2008;25(4):285-294. X-1, X-5.
394 Delmonico RL, Hanley-Peterson P, Englander J. Group psychotherapy for persons with traumatic brain injury: management of frustration and substance abuse. J Head Trauma Rehabil. 12. 1998;13(6):10-22. X-1, X-2. [pmid: 9885315].
395 Demakis GJ, Hammond F, Knotts A, et al. The Personality Assessment Inventory in individuals with traumatic brain injury. Arch Clin Neuropsychol. 01. 2007;22(1):123-30. X-1. [pmid: 17182214].
396 Demaree HA, Crews WD Jr, Harrison DW. Topographical brain mapping in depression following mild closed head injury: A case study. Journal of Neurotherapy. Sum. 1995;1(1):38-43. X-5.
397 DePalo R. The role of hope and spirituality on the road to recovery. Exceptional Parent. 02. 2009;39(2):74-7. X-1, X-2.
398 DePrince AP, Weinzierl KM, Combs MD. Executive function performance and trauma exposure in a community sample of children. Child Abuse Negl. 06. 2009;33(6):353-61. X-3. [pmid: 19477515].
399 Dept. of the Army -- USAMRAA. Psychological Health and Traumatic Brain Injury Advanced Technology/Therapeutic Devleopment Award. 2009. 07. 7. 2010. 02. 9. X-7.
400 Dhikav V, Anand KS. Is hippocampal atrophy a future drug target. Med Hypotheses. 2007;68(6):1300-6. X-1, X-2. [pmid: 17098374].
401 Diaconescu R, Flowers CR, Storer B, et al. Morbidity and mortality with nonmyeloablative compared with myeloablative conditioning before hematopoietic cell transplantation from HLA-matched related donors. Blood. 2004;104(5):1550-1558. X-1. [pmid: 15150081].
402 Diaz AL. Do I know you? A case study of prosopagnosia (face blindness). Journal of School Nursing. 2008 SCH NURS (SAGE)). 10. 2008;24(5):284-9. X-1, X-3, X-5.
403 Dichter MA, Locke RE. Clinical trials in neuroprotection. 23–25 January 2003. Key Biscayne, Florida, USA. Expert Opin Emerg Drugs. 05. 2003;8(1):267-71. X-1, X-2.
404 Dick FD, De Palma G, Ahmadi A, et al. Environmental risk factors for Parkinson’s disease and parkinsonism: the Geoparkinson study. Occup Environ Med. 10. 2007;64(10):666-72. X-1, X-5. [pmid: 17332139].
405 Dikmen S, Machamer J, Miller B, et al. Functional status examination: a new instrument for assessing outcome in traumatic brain injury. J Neurotrauma. 02. 2001;18(2):127-40. X-1, X-4. [pmid: 11229707].
406 Dikmen S, Reitan RM. Psychological deficits and recovery of functions after head injury. Trans Am Neurol Assoc. 1976;101:72-7. X-1, X-5. [pmid: 1028272].
407 Dikmen SS, Bombardier CH, Machamer JE, et al. Natural history of depression in traumatic brain injury. Arch Phys Med Rehabil. 09. 2004;85(9):1457-64. X-1. [pmid: 15375816].
408 Dikmen SS, Machamer JE, Powell JM, et al. Outcome 3 to 5 years after moderate to severe traumatic brain injury. Arch Phys Med Rehabil. 10. 2003;84(10):1449-57. X-1. [pmid: 14586911].
409 Dikmen SS, Machamer JE, Winn HR, et al. Neuropsychological effects of valproate in traumatic brain injury: a randomized trial. Neurology. 02. 22. 2000;54(4):895-902. X-1. [pmid: 10690983].
410 Dinan TG, Mobayed M. Treatment resistance of depression after head injury: a preliminary study of amitriptyline response. Acta Psychiatr Scand. 04. 1992;85(4):292-4. X-5. [pmid: 1595364].
411 Dixon MR, Guercio J, Falcomata T, et al. Exploring the Utility of Functional Analysis Methodology to Assess and Treat Problematic Verbal Behavior in Persons with Acquired Brain Injury. Behavioral Interventions. 04. 2004;19(2):91-102. X-5.
412 Doczy EJ, Seroogy K, Harrison CR, et al. Hypothalamo-pituitary-adrenocortical axis, glucocorticoids, and neurologic disease. Immunology and Allergy Clinics of North America. 05. 2009;29(2):265-284. X-1. [pmid: 19389581].
413 Dolberg OT, Barkai G, Gross Y, et al. Differential effects of topiramate in patients with traumatic brain injury and obesity--a case series. Psychopharmacology (Berl). 06. 2005;179(4):838-45. X-1, X-5. [pmid: 15619108].
414 Dolberg OT, Klag E, Gross Y, et al. Relief of serotonin selective reuptake inhibitor induced sexual dysfunction with low-dose mianserin in patients with traumatic brain injury. Psychopharmacology. 2002;161(4):404-407. X-5. [pmid: 12073168].
415 Dolinak D, Wise SH, Jones C. Microscopic and spectroscopic features of gunpowder and its documentation in gunshot wounds in charred bodies. Am J Forensic Med Pathol. 12. 2008;29(4):312-9. X-1. [pmid: 19259016].
416 Dolinar LJ. Delusions in a patient with post-traumatic headache. Psychosomatics. Fall. 1991;32(4):460-2. X-1, X-2, X-5. [pmid: 1961865].
417 Doll D, Bowley DM. Veterans’ health--surviving acute injuries is not enough. Lancet. 03. 29. 2008;371(9618):1053-5. X-1, X-2, X-4, X-5. [pmid: 18374826].
418 Doman G, Wilkinson R, Dimancescu MD, et al. The effect of intense multi-sensory stimulation on coma arousal and recovery. Neuropsychological Rehabilitation. 1993;3(2):203-212. X-1.
419 Donahue DJ, Muhlbauer MS, Kaufman RA, et al. Childhood survival of atlantooccipital dislocation: underdiagnosis, recognition, treatment, and review of the literature. Pediatr Neurosurg. 1994;21(1):105-11. X-1, X-3, X-5. [pmid: 7947302].
420 Donders J, Boonstra T. Correlates of invalid neuropsychological test performance after traumatic brain injury. Brain Inj. 03. 2007;21(3):319-26. X-1. [pmid: 17453760].
421 Donnellan CP. Acupuncture for central pain affecting the ribcage following traumatic brain injury and rib fractures--a case report. Acupunct Med. 09. 2006;24(3):129-33. X-5. [pmid: 17013360].
422 Donnelly JP, Donnelly K, Grohman KK. A multi-perspective concept mapping study of problems associated with traumatic brain injury. Brain Inj. 12. 2005;19(13):1077-85. X-1, X-5. [pmid: 16286321].
423 Dosoglu M, Orakdogen M, Somay H, et al. Civilian gunshot wounds to the head. Neurochirurgie. 09. 1999;45(3):201-7. X-1, X-5. [pmid: 10567959].
424 Doty RL, Yousem DM, Pham LT, et al. Olfactory dysfunction in patients with head trauma. Arch Neurol. 09. 1997;54(9):1131-40. X-1. [pmid: 9311357].
425 Douglas JM, Spellacy FJ. Indicators of long-term family functioning following severe traumatic brain injury in adults. Brain Inj. 11. 1996;10(11):819-39. X-5. [pmid: 8905160].
426 Douglas JM, Spellacy FJ. Correlates of depression in adults with severe traumatic brain injury and their carers. Brain Inj. 01. 2000;14(1):71-88. X-5. [pmid: 10670663].
427 Douglas JM, Spellacy FJ. “Correlates of depression in adults with severe traumatic brain injury and their carers”:”. Erratum. Brain Injury. 02. 2000;14(2):204. X-2, X-5.
428 Dragunow M, Goulding M, Faull RL, et al. Induction of c-fos mRNA and protein in neurons and glia after traumatic brain injury: pharmacological characterization. Exp Neurol. 03. 1990;107(3):236-48. X-1, X-4, X-5. [pmid: 2106445].
429 Drake AI, McDonald EC, Magnus NE, et al. Utility of Glasgow Coma Scale-Extended in symptom prediction following mild traumatic brain injury. Brain Inj. 05. 2006;20(5):469-75. X-1. [pmid: 16716993].
430 Draper K, Ponsford J, Schonberger M. Psychosocial and emotional outcomes 10 years following traumatic brain injury. J Head Trauma Rehabil. 09–10. 2007;22(5):278-87. X-1. [pmid: 17878769].
431 Driver S, Ede A. Impact of physical activity on mood after TBI. Brain Inj. 03. 2009;23(3):203-12. X-5. [pmid: 19205956].
432 Driver S, Lox C. Establishing the reliability and validity of a measure of mood for adults with brain injuries. Journal of Cognitive Rehabilitation. 2006;24(4):4-10. X-1.
433 Drory Y, Ouaknine G, Kosary IZ, et al. Electrocardiographic findings in brain death; description and presumed mechanism. Chest. 04. 1975;67(4):425-32. X-1, X-5. [pmid: 1122770].
434 Druid H. Site of entrance wound and direction of bullet path in firearm fatalities as indicators of homicide versus suicide. Forensic Science International. 1997;88(2):147-162. X-1. [pmid: 9251234].
435 Drury B. The new unknown soldiers. Men’s Health. 03. 2009;24(2):126-32. X-2.
436 du Boulay GH. Indications for plain skull X-rays. Br J Hosp Med. 03. 1977;17(3):272-9. X-1. [pmid: 851678].
437 du Plessis JJ. Percutaneous pharyngostomy versus gastric tube placement in head injured patients. A prospective comparative study of 50 patients. Acta Neurochir (Wien). 1992;119(1–4):94-6. X-1, X-4. [pmid: 1481761].
438 Ducharme JM, Spencer T, Davidson A, et al. Errorless compliance training: building a cooperative relationship between parents with brain injury and their oppositional children. Am J Orthopsychiatry. 10. 2002;72(4):585-95. X-1, X-5. [pmid: 15792043].
439 Duckro PN, Chibnall JT. Chronic daily headache as a sequela of minor head and/or neck trauma: A multiple case study. Headache Quarterly. 1995;6(4):297-302. X-1, X-5.
440 Duckro PN, Chibnall JT, Tomazic TJ. Anger, depression, and disability: a path analysis of relationships in a sample of chronic posttraumatic headache patients. Headache. 01. 1995;35(1):7-9. X-1. [pmid: 7868342].
441 Duh MS, Paradis PE, Latremouille-Viau D, et al. The risks and costs of multiple-generic substitution of topiramate. Neurology. 2009;72(24):2122-2129. X-1. [pmid: 19528520].
442 Duma SJ, Reger MA, Canning SS, et al. Longitudinal mental health screening results among postdeployed U.S. soldiers preparing to deploy again. Journal of Traumatic Stress. 02. 2010;23(1):52-58. X-1. [pmid: 20146258].
443 Dundon M. From the patient’s point of view. Journal of Cognitive Rehabilitation. 03–04. 1996;14(2):4-5. X-2.
444 Dunn T, Arie T. Mental disturbance in the ill old person. Br Med J. 11. 17. 1973;4(5889):413-6. X-1. [pmid: 4749785].
445 Dupuis O, Silveira R, Dupont C, et al. Comparison of “instrument-associated” and “spontaneous” obstetric depressed skull fractures in a cohort of 68 neonates. Am J Obstet Gynecol. 01. 2005;192(1):165-70. X-1, X-3. [pmid: 15672020].
446 Dworetzky BA, Strahonja-Packard A, Shanahan CW, et al. Characteristics of male veterans with psychogenic nonepileptic seizures. Epilepsia. 09. 2005;46(9):1418-22. X-1. [pmid: 16146437].
447 Eastwood EA, Schechtman J. Direct observation nursing: adverse patient behaviors and functional outcomes. Nurs Econ. 03–04. 1999;17(2):96-102. X-1. [pmid: 10410028].
448 Eberhardie C. Research roundup Sleep disturbances, headaches and mood alterations in mild TBI. British Journal of Neuroscience Nursing. 09. 2009;5(9):437. X-2.
449 Eby GA, Eby KL. Rapid recovery from major depression using magnesium treatment. Medical Hypotheses. 2006;67(2):362-370. X-1, X-2. [pmid: 16542786].
450 Edwards DJ. Sometimes it’s not a behavioral health diagnosis. Behav Healthc. 03. 2006;26(3):40. X-1, X-2, X-4, X-5.
451 Edwards DW, Dahmen BA, Wanlass RL, et al. Personality assessment in neuropsychology: the nonspecificity of MMPI-2 neurocorrection methods. Assessment. 09. 2003;10(3):222-7. X-1, X-5. [pmid: 14503645].
452 Ehrlich S, Noam GG, Lyoo IK, et al. White matter hyperintensities and their associations with suicidality in psychiatrically hospitalized children and adolescents. J Am Acad Child Adolesc Psychiatry. 06. 2004;43(6):770-6. X-1, X-3. [pmid: 15167094].
453 Ehrt O, Boergen KP. A concept for the surgical treatment of trochlear palsy. Strabismus. 06. 2004;12(2):75-83. X-1. [pmid: 15672930].
454 Eidelman I, Seedat S, Stein DJ. Risperidone in the treatment of acute stress disorder in physically traumatized in-patients. Depress Anxiety. 2000;11(4):187-8. X-1, X-5. [pmid: 10945142].
455 Eisenberg L. Prevention: rhetoric and reality. J R Soc Med. 04. 1984;77(4):268-80. X-1. [pmid: 6425497].
456 Eitinger L. Psychosomatic problems in concentration camp survivors. J Psychosom Res. 06. 1969;13(2):183-9. X-1. [pmid: 5789611].
457 Eitinger L. Organic and psychosomatic aftereffects of conentration camp imprisonment. Int Psychiatry Clin. 1971;8(1):205-15. X-1. [pmid: 5148251].
458 Elbaum-David J. Self-awareness of memory impairment, depression and short-term memory in adults with traumatic brain injury. New York University. 1997:117. X-7.
459 Elias-Jones AC, Punt JA, Turnbull AE, et al. Management and outcome of severe head injuries in the Trent region 1985–90. Arch Dis Child. 12. 1992;67(12):1430-5. X-1, X-3, X-5. [pmid: 1489220].
460 Ell PJ, Costa DC. The role of nuclear medicine in neurology and psychiatry. Current Opinion in Neurology & Neurosurgery. 1992;5(6):863-869. X-1, X-2. [pmid: 1467580].
461 Elliott TR. Registering Randomized Clinical Trials and the Case for CONSORT. Experimental & Clinical Psychopharmacology. 2007;15(6):511-518. X-1, X-2. [pmid: 18179303].
462 Ellis A, Stores G, Mayou R. Psychological consequences of road traffic accidents in children. Eur Child Adolesc Psychiatry. 06. 1998;7(2):61-8. X-3, X-5. [pmid: 9712371].
463 Ellis-Hill CS, Horn S. Change in identity and self-concept: a new theoretical approach to recovery following a stroke. Clin Rehabil. 06. 2000;14(3):279-87. X-1. [pmid: 10868723].
464 Elovic E, Doppalapudi HS, Miller M, et al. Endocrine abnormalities and fatigue after traumatic brain injury. Journal of Head Trauma Rehabilitation. 2006;21(5):426-7. X-1, X-2, X-5.
465 Emilien G, Waltregny A. Traumatic brain injury, cognitive and emotional dysfunction. Impact of clinical neuropsychology research. Acta Neurol Belg. 06. 1996;96(2):89-101. X-5. [pmid: 8711991].
466 Engberg AW, Teasdale TW. A population-based study of survival and discharge status for survivors after head injury. Acta Neurol Scand. 11. 2004;110(5):281-90. X-1, X-4. [pmid: 15476456].
467 Engberg AW, Teasdale TW. Psychosocial outcome following traumatic brain injury in adults: a long-term population-based follow-up. Brain Inj. 06. 2004;18(6):533-45. X-1. [pmid: 15204335].
468 Engstad T, Bonaa KH, Viitanen M. Validity of self-reported stroke : The Tromso Study. Stroke. 07. 2000;31(7):1602-7. X-1. [pmid: 10884460].
469 Eriksson G, Kottorp A, Borg J, et al. Relationship between occupational gaps in everyday life, depressive mood and life satisfaction after acquired brain injury. J Rehabil Med. 02. 2009;41(3):187-94. X-5. [pmid: 19229453].
470 Estes R. Preventative care: psychological factors affecting behavior: depression after brain injury. Premier Outlook. Summer. 2004;4(2):57-62. X-1, X-2, X-4, X-5.
471 Esty ML. Treatment results for mild/moderate traumatic brain injury using EEG data provides quantitative information with predictive value for rehabilitation outcomes and treatment planning. Premier Outlook. Winter. 2002;3(4):56-8. X-5.
472 Ettenhofer ML, Abeles N. The significance of mild traumatic brain injury to cognition and self-reported symptoms in long-term recovery from injury. J Clin Exp Neuropsychol. 04. 2009;31(3):363-72. X-1. [pmid: 18618356].
473 Ettinger AB, Copeland LA, Zeber JE, et al. Are psychiatric disorders independent risk factors for new-onset epilepsy in older individuals. Epilepsy Behav. 01. 2010;17(1):70-4. X-1, X-5. [pmid: 19913462].
474 Evans CC, Sherer M, Nakase-Richardson R, et al. Evaluation of an interdisciplinary team intervention to improve therapeutic alliance in post-acute brain injury rehabilitation. J Head Trauma Rehabil. 09–10. 2008;23(5):329-38. X-1. [pmid: 18815509].
475 Evans J, Vaillant JM, Bertrand JC, et al. The reduction of zygomatic fractures using a straight mouth gag. J Oral Surg. 04. 1979;37(4):274-5. X-1, X-2. [pmid: 285234].
476 Evans RW. Posttraumatic headaches among United States soldiers injured in Afghanistan and Iraq. Headache. 2008;48(8):1216-1225. X-1, X-2. [pmid: 18808502].
477 Evans RW, Gualtieri CT, Patterson DR. Treatment of chronic closed head injury with psychostimulant drugs: A controlled case study and an appropriate evaluation procedure. Journal of Nervous and Mental Disease. 02. 1987;175(2):106-110. X-5. [pmid: 3543216].
478 Ewing-Cobbs L, Levin HS, Eisenberg HM, et al. Language functions following closedhead injury in children and adolescents. J Clin Exp Neuropsychol. 10. 1987;9(5):575-92. X-1, X-3. [pmid: 2444619].
479 Fabricius M, Fuhr S, Bhatia R, et al. Cortical spreading depression and peri-infarct depolarization in acutely injured human cerebral cortex. Brain. 03. 2006;129(Pt 3):778-90. X-1, X-5. [pmid: 16364954].
480 Fabricius M, Fuhr S, Willumsen L, et al. Association of seizures with cortical spreading depression and peri-infarct depolarisations in the acutely injured human brain. Clin Neurophysiol. 09. 2008;119(9):1973-84. X-1. [pmid: 18621582].
481 Fahy TJ, Irving MH, Millac P. Severe head injuries. A six-year follow-up. Lancet. 09. 2. 1967;2(7514):475-9. X-1, X-4, X-5. [pmid: 4166405].
482 Fals-Stewart W, Bates ME. The neuropsychological test performance of drug-abusing patients: an examination of latent cognitive abilities and associated risk factors. Exp Clin Psychopharmacol. 02. 2003;11(1):34-45. X-1. [pmid: 12622342].
483 Famularo R, Fenton T, Kinscherff R. Medical and developmental histories of maltreated children. Clin Pediatr (Phila). 09. 1992;31(9):536-41. X-1, X-3. [pmid: 1468170].
484 Fann JR, Burington B, Leonetti A, et al. Psychiatric illness following traumatic brain injury in an adult health maintenance organization population. Arch Gen Psychiatry. 01. 2004;61(1):53-61. X-1, X-4. [pmid: 14706944].
485 Fann JR, Hart T, Schomer KG. Treatment for depression after traumatic brain injury: a systematic review. J Neurotrauma. 12. 2009;26(12):2383-402. X-7. [pmid: 19698070].
486 Fann JR, Leonetti A, Jaffe K, et al. Psychiatric illness and subsequent traumatic brain injury: a case control study. J Neurol Neurosurg Psychiatry. 05. 2002;72(5):615-20. X-1. [pmid: 11971048].
487 Fann JR, Uomoto JM, Katon WJ. Sertraline in the treatment of major depression following mild traumatic brain injury. J Neuropsychiatry Clin Neurosci. Spring. 2000;12(2):226-32. X-1, X-5. [pmid: 11001601].
488 Fann JR, Uomoto JM, Katon WJ. Cognitive improvement with treatment of depression following mild traumatic brain injury. Psychosomatics. 01–02. 2001;42(1):48-54. X-5. [pmid: 11161121].
489 Farrin L, Hull L, Unwin C, et al. Effects of depressed mood on objective and subjective measures of attention. J Neuropsychiatry Clin Neurosci. Winter. 2003;15(1):98-104. X-1. [pmid: 12556579].
490 Fauerbach JA, Heinberg LJ, Lawrence JW, et al. Effect of early body image dissatisfaction on subsequent psychological and physical adjustment after disfiguring injury. Psychosom Med. 07–08. 2000;62(4):576-82. X-1. [pmid: 10949104].
491 Fear NT, Jones E, Groom M, et al. Symptoms of post-concussional syndrome are nonspecifically related to mild traumatic brain injury in UK Armed Forces personnel on return from deployment in Iraq: an analysis of self-reported data. Psychol Med. 08. 2009;39(8):1379-87. X-1. [pmid: 18945380].
492 Feeney TJ, Ylvisaker M, Rosen BH, et al. Community supports for individuals with challenging behavior after brain injury: an analysis of the New York state behavioral resource project. J Head Trauma Rehabil. 02. 2001;16(1):61-75. X-1. [pmid: 11277851].
493 Feinstein A, Ouchterlony D, Somerville J, et al. The effects of litigation on symptom expression: a prospective study following mild traumatic brain injury. Med Sci Law. 04. 2001;41(2):116-21. X-1. [pmid: 11368391].
494 Feldman M. The post-concussional syndrome--fact or fancy. S Afr Med J. 11. 24. 1973;47(46):2247-8. X-1. [pmid: 4760920].
495 Felicetti TC. Suicidal threats by brain damaged clients: A facility responds. Residential Treatment for Children & Youth. 1990;7(3):5-10. X-3.
496 Fenimore EA. Depression following traumatic brain injury and the Hamilton Depression Rating Scale. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2006;67(3-B). X-7.
497 Fenske TS, Kahl BS, Eickhoff J, et al. Excessive toxicity of the high dose thiotepa and etoposide regimen when combined with radiation: Long-term autologous transplantation experience in follicular and mantle cell lymphoma. Leukemia & Lymphoma. 2005;46(10):1441-1448. X-1, X-5. [pmid: 16194889].
498 Ferguson RJ, Mittenberg W, Barone DF, et al. Postconcussion syndrome following sports-related head injury: expectation as etiology. Neuropsychology. 10. 1999;13(4):582-9. X-6. [pmid: 10527067].
499 Ferlazzo E, Morgante F, Rizzo V, et al. Successful treatment of Holmes tremor by levetiracetam. Movement Disorders. 2008;23(14):2101-2103. X-1. [pmid: 18785235].
500 Ferreira MC, Besteiro JM, Tuma Junior P. Results of reconstruction of the facial nerve. Microsurgery. 1994;15(1):5-8. X-1. [pmid: 8133769].
501 Ferrier-Auerbach AG, Erbes CR, Polusny MA, et al. Predictors of emotional distress reported by soldiers in the combat zone. Journal of Psychiatric Research. Published online 2009, 24. X-1.
502 Ferry C, Gemayel G, Rocha V, et al. Long-term outcomes after allogeneic stem cell transplantation for children with hematological malignancies. Bone Marrow Transplant. 08. 2007;40(3):219-24. X-1, X-3. [pmid: 17530002].
503 Fichtenberg NL, Millis SR, Mann NR, et al. Factors associated with insomnia among post-acute traumatic brain injury survivors. Brain Inj. 07. 2000;14(7):659-67. X-1. [pmid: 10914647].
504 Fichtenberg NL, Zafonte RD, Putnam S, et al. Insomnia in a post-acute brain injury sample. Brain Inj. 03. 2002;16(3):197-206. X-1. [pmid: 11874613].
505 Fictenberg NL, Putnam SH, Mann NR, et al. Insomnia screening in postacute traumatic brain injury: utility and validity of the Pittsburgh Sleep Quality Index. Am J Phys Med Rehabil. 05. 2001;80(5):339-45. X-1. [pmid: 11327555].
506 Fildes J, Reed L, Jones N, et al. Trauma: the leading cause of maternal death. J Trauma. 05. 1992;32(5):643-5. X-1. [pmid: 1588654].
507 Filipovic B, Kovacevic S, Stojicic M, et al. Morphological differences among cavum septi pellucidi obtained in patients with schizophrenia and healthy individuals: forensic implications. A post-mortem study. Psychiatry Clin Neurosci. 02. 2005;59(1):106-8. X-1. [pmid: 15679549].
508 Fineschi V, Agricola E, Baroldi G, et al. Myocardial findings in fatal carbon monoxide poisoning: a human and experimental morphometric study. Int J Legal Med. 2000;113(5):276-82. X-1. [pmid: 11009063].
509 Finger S, Clower WT. Victor Horsley on “trephining in pre-historic times”. Neurosurgery. 04. 2001;48(4):911-7. discussion 917–8. X-1, X-2. [pmid: 11322452].
510 Finger S, Koehler PJ, Jagella C. The Monakow concept of diaschisis: origins and perspectives. Arch Neurol. 02. 2004;61(2):283-8. X-1, X-2. [pmid: 14967781].
511 Finlayson MA. Clinical neuropsychology in rehabilitation. Ontario Psychologist. 04. 1985;17(2):15-19. X-2.
512 Finlayson MA, Sullivan JF, Alfano DP. Halstead. ’s Category Test: withstanding the test of time, J Clin Exp Neuropsychol. 12. 1986;8(6):706-9. X-1.
513 Finset A, Andersson S. Coping strategies in patients with acquired brain injury: relationships between coping, apathy, depression and lesion location. Brain Inj. 10. 2000;14(10):887-905. X-1, X-5. [pmid: 11076135].
514 Fishbain DA, Fletcher JR, Aldrich TE, et al. Relationship between Russian roulette deaths and risk-taking behavior: a controlled study. Am J Psychiatry. 05. 1987;144(5):563-7. X-1, X-5. [pmid: 3578564].
515 Fisher L, Macnaughton PD. Electrolyte and metabolic disturbances in the critically ill. Anaesthesia & Intensive Care Medicine. 2006;7(5):151-154. X-1, X-2.
516 Flach J, Malmros R. A long-term follow-up study of children with severe head injury. Scand J Rehabil Med. 1972;4(1):9-15. X-1. [pmid: 4643596].
517 Flanagan DA. A retrospective analysis of expressed emotion (EE) and affective distress in a sample of relatives caring for traumatically brain-injured (TBI) family members. Br J Clin Psychol. 11. 1998;37(Pt 4):431-9. X-1, X-5. [pmid: 9856296].
518 Fleming J, Kuipers P, Foster M, et al. Evaluation of an outpatient, peer group intervention for people with acquired brain injury based on the ICF ‘Environment’ dimension. Disabil Rehabil. 2009;31(20):1666-75. X-1, X-5. [pmid: 19479533].
519 Fleming JM, Strong J, Ashton R. Cluster analysis of self-awareness levels in adults with traumatic brain injury and relationshipto outcome. J Head Trauma Rehabil. 10. 1998;13(5):39-51. X-1. [pmid: 9753534].
520 Fleminger S, Oliver DL, Williams WH, et al. The neuropsychiatry of depression after brain injury. Neuropsychological Rehabilitation. 2003;13(1–2):65-87. X-2. [pmid: 21854328].
521 Foley J, Garcia J, Harris K, et al. Can the MMPI-2 discriminate between mild-moderate TBI and other neurologic and psychiatric populations. Int J Neurosci. 12. 2006;116(12):1377-89. X-1. [pmid: 17145674].
522 Folmer RL, Griest SE. Chronic tinnitus resulting from head or neck injuries. Laryngoscope. 05. 2003;113(5):821-7. X-1. [pmid: 12792317].
523 Folstein MF, Folstein SE, McHugh PR. “Mini-mental state”. A practical method for grading the cognitive state of patients for the clinician. J Psychiatr Res. 11. 1975;12(3):189-98. X-1. [pmid: 1202204].
524 Fordyce DJ, Roueche JR, Prigatano GP. Enhanced emotional reactions in chronic head trauma patients. J Neurol Neurosurg Psychiatry. 07. 1983;46(7):620-4. X-4. [pmid: 6886698].
525 Fork M, Bartels C, Ebert AD, et al. Neuropsychological sequelae of diffuse traumatic brain injury. Brain Inj. 02. 2005;19(2):101-8. X-1. [pmid: 15841754].
526 Forman ACM, Vesey PA, Lincoln NB. Effectiveness of an adjustment group for brain injury patients: a pilot evaluation. International Journal of Therapy & Rehabilitation. 2006;13(5):223-8. X-5.
527 Formisano R, Bivona U, Catani S, et al. Post-traumatic headache: facts and doubts. Journal of Headache and Pain. Published online 18 March 2009. 2009. X-2.
528 Forsgren L, Nystrom L. An incident case-referent study of epileptic seizures in adults. Epilepsy Res. 05–06. 1990;6(1):66-81. X-1. [pmid: 2357957].
529 Fortin A, Lefebvre MB, Ptito M. Traumatic brain injury and olfactory deficits: The tale of two smell tests!. Brain Injury. 01. 2010;24(1):27-33. X-1, X-5. [pmid: 20001480].
530 Fraas M, Balz MA. Expressive electronic journal writing: freedom of communication for survivors of acquired brain injury. J Psycholinguist Res. 03. 2008;37(2):115-24. X-1, X-5. [pmid: 18004660].
531 Francisco GE, Walker WC, Zasler ND, et al. Pharmacological management of neurobehavioural sequelae of traumatic brain injury: A survey of current physiatric practice. Brain Injury. 2007;21(10):1007-1014. X-1. [pmid: 17891562].
532 Frank RG, Wonderlich SA, Corcoran JR, et al. Interpersonal response to spinal cord injury. Journal of Social & Clinical Psychology. 1986;4(4):447-460. X-1, X-2.
533 Franzini A, Messina G, Leone M, et al. Feasibility of simultaneous vagal nerve and deep brain stimulation in chronic cluster headache: Case report and considerations. Neurological Sciences. 05. 2009;30(Suppl1):S137-S139. X-1, X-5. [pmid: 19415445].
534 Freedman D, Hemenway D. Precursors of lethal violence: a death row sample. Soc Sci Med. 06. 2000;50(12):1757-70. X-1, X-5. [pmid: 10798330].
535 Freeman MR, Ryan JJ, Lopez SJ, et al. Cognitive estimation in traumatic brain injury: relationships with measures of intelligence, memory, and affect. Int J Neurosci. 12. 1995;83(3–4):269-73. X-5. [pmid: 8869432].
536 Freeman T, High WM. Treatment of a patient with traumatic brain injury-related severe self-injurious behavior. Journal of Head Trauma Rehabilitation. 2009;24(4):292-296. X-5. [pmid: 19625868].
537 Freemon FR. Evaluation of patients with progressive intellectual deterioration. Arch Neurol. 09. 1976;33(9):658-9. X-1. [pmid: 134683].
538 Freemon FR, Rudd SM. Clinical features that predict potentially reversible progressive intellectual deterioration. J Am Geriatr Soc. 07. 1982;30(7):449-51. X-1. [pmid: 7086025].
539 Frey LC. Epidemiology of posttraumatic epilepsy: a critical review. Epilepsia. 2003;44(Suppl 10):11-7. X-1, X-2, X-4, X-5. [pmid: 14511389].
540 Frieboes RM, Muller U, Murck H, et al. Nocturnal hormone secretion and the sleep EEG in patients several months after traumatic brain injury. J Neuropsychiatry Clin Neurosci. Summer. 1999;11(3):354-60. X-1, X-5. [pmid: 10440012].
541 Frigerio R, Fujishiro H, Maraganore DM, et al. Comparison of risk factor profiles in incidental Lewy body disease and Parkinson disease. Arch Neurol. 09. 2009;66(9):1114-9. X-1. [pmid: 19752300].
542 Fromm L, Heath DL, Vink R, et al. Magnesium attenuates post-traumatic depression/anxiety following diffuse traumatic brain injury in rats. J Am Coll Nutr. 10. 2004;23(5):529S-533S. X-3, X-5. [pmid: 15466958].
543 Gaidolfi E, Vignolo LA. Closed head injuries of school-age children: neuropsychological sequelae in early adulthood. Ital J Neurol Sci. 03. 1980;1(2):65-73. X-3, X-5. [pmid: 7338453].
544 Galbraith S, Murray WR, Patel AR, et al. The relationship between alcohol and head injury and its effect on the conscious level. Br J Surg. 02. 1976;63(2):128-30. X-1. [pmid: 1252711].
545 Gallagher R, Drance E, Higginbotham S. Finding the Person Behind the Pain: Chronic Pain Management in a Patient With Traumatic Brain Injury. Journal of the American Medical Directors Association. 2006;7(7):432-434. X-1, X-2, X-5. [pmid: 16979087].
546 Galski T, Palasz J, Bruno RL, et al. Predicting physical and verbal aggression on a brain trauma unit. Arch Phys Med Rehabil. 04. 1994;75(4):380-3. X-5. [pmid: 8172494].
547 Garniak A, Feivel M, Hertz M, et al. Skull x-rays in head trauma: are they still necessary? A review of 1000 cases. Eur J Radiol. 05. 1986;6(2):89-91. X-1. [pmid: 3720752].
548 Garske GG, Thomas KR. Self-reported self-esteem and depression: Indexes of psychosocial adjustment following severe traumatic brain injury. Rehabilitation Counseling Bulletin. 09. 1992;36(1):44-52. X-5.
549 Gass CS, Apple C. Cognitive complaints in closed-head injury: relationship to memory test performance and emotional disturbance. J Clin Exp Neuropsychol. 04. 1997;19(2):290-9. X-1. [pmid: 9240487].
550 Gass CS, Russell EW. MMPI correlates of performance intellectual deficits in patients with right hemisphere lesions. J Clin Psychol. 09. 1987;43(5):484-9. X-1, X-5. [pmid: 3667941].
551 Gatsoulis N, Tzafestas N, Damaskinos A. Pre-hospital trauma deaths in a tourist region in Greece. Pre hospital. Immediate Care. 2000;4(3):117-21. X-1, X-5.
552 Gauggel S, Wietasch A, Bayer C, et al. The impact of positive and negative feedback on reaction time in brain-damaged patients. Neuropsychology. 01. 2000;14(1):125-33. X-1. [pmid: 10674804].
553 Gaylin W, et al. The law and the biological revolution. Columbia J Law Soc Probl. Fall. 1973;10(1):47-76. X-1. [pmid: 11664303].
554 Gelbart AO, Schwarz SB. The elderly patient with dementia. Am Fam Physician. 01. 1981;23(1):196-9. X-1. [pmid: 7457315].
555 Gemmell C, Leathem JM. A study investigating the effects of Tai Chi Chuan: individuals with traumatic brain injury compared to controls. Brain Inj. 02. 2006;20(2):151-6. X-1, X-5. [pmid: 16421063].
556 Geraldina P, Mariarosaria L, Annarita A, et al. Neuropsychiatric sequelae in TBI: a comparison across different age groups. Brain Inj. 10. 2003;17(10):835-46. X-3. [pmid: 12963550].
557 Gerdine LV. Osteopathy and insanity. 1917. J Am Osteopath Assoc. 08. 2000;100(8):499-500. X-1. [pmid: 10979257].
558 Gerlock AJ, Sinn DP. Anatomic, clinical, surgical, and radiographic correlation of the zygomatic complex fracture. AJR Am J Roentgenol. 02. 1977;128(2):235-8. X-1, X-2. [pmid: 401608].
559 Gerring JP, Slomine B, Vasa RA, et al. Clinical predictors of posttraumatic stress disorder after closed head injury in children. J Am Acad Child Adolesc Psychiatry. 02. 2002;41(2):157-65. X-1, X-3. [pmid: 11837405].
560 Gervais RO, Ben-Porath YS, Wygant DB, et al. Development and validation of a Response Bias Scale (RBS) for the MMPI-2. Assessment. 06. 2007;14(2):196-208. X-1. [pmid: 17504891].
561 Gervais RO, Ben-Porath YS, Wygant DB, et al. Differential sensitivity of the Response Bias Scale (RBS) and MMPI-2 validity scales to memory complaints. Clin Neuropsychol. 12. 2008;22(6):1061-79. X-1. [pmid: 18609315].
562 Geurtsen GJ, Martina JD, Van Heugten CM, et al. A prospective study to evaluate a new residential community reintegration programme for severe chronic brain injury: the Brain Integration Programme. Brain Inj. 07. 2008;22(7–8):545-54. X-1, X-5. [pmid: 18568707].
563 Gfeller JD, Chibnall JT, Duckro PN. Postconcussion symptoms and cognitive functioning in posttraumatic headache patients. Headache. 10. 1994;34(9):503-7. X-5. [pmid: 8002321].
564 Gibson L, MacLennan WJ, Gray C, et al. Evaluation of a comprehensive assessment battery for stroke patients. Int J Rehabil Res. 1991;14(2):93-100. X-1, X-5. [pmid: 1938029].
565 Gibson TC. Skull X-rays in minor head injury. A review of their use and interpretation by casualty officers. Scott Med J. 04. 1983;28(2):132-7. X-1. [pmid: 6867691].
566 Gil S, Caspi Y, Ben-Ari IZ, et al. Does memory of a traumatic event increase the risk for posttraumatic stress disorder in patients with traumatic brain injury? A prospective study. Am J Psychiatry. 05. 2005;162(5):963-9. X-1. [pmid: 15863799].
567 Gilbody S, Richards D, Brealey S, et al. Screening for depression in medical settings with the Patient Health Questionnaire (PHQ): a diagnostic meta-analysis. J Gen Intern Med. 11. 2007;22(11):1596-602. X-1, X-2, X-4, X-5. [pmid: 17874169].
568 Gilchrist E, Wilkinson M. Some factors determining prognosis in young people with severe head injuries. Arch Neurol. 06. 1979;36(6):355-9. X-1. [pmid: 454233].
569 Giles GM, Mohr JD. Overview and inter-rater reliability of an incident-based rating scale for aggressive behaviour following traumatic brain injury: The Overt Aggression Scale-Modified for Neurorehabilitation-Extended (OAS-MNR-E). Brain Inj. 05. 2007;21(5):505-11. X-1, X-5. [pmid: 17522990].
570 Gill JR, Lenz KA, Amolat MJ. Gunshot fatalities in children and adolescents in New York City. J Forensic Sci. 07. 2003;48(4):832-5. X-1, X-3. [pmid: 12877302].
571 Gillen R, Tennen H, Affleck G, et al. Distress, depressive symptoms, and depressive disorder among caregivers of patients with brain injury. J Head Trauma Rehabil. 06. 1998;13(3):31-43. X-1. [pmid: 9582177].
572 Gillespie MP, Trzepacz PT. Head trauma, affective syndrome in a patient with MS. Psychosomatics: Journal of Consultation Liaison Psychiatry. 06. 1985;26(6):531-532. X-1, X-5.
573 Gilpin DA, Nelson PG. Revised trauma score: a triage tool in the accident and emergency department. Injury. 01. 1991;22(1):35-7. X-1. [pmid: 2030028].
574 Ginzburg HM, Holm KD. The struggle for DoD/VA benefits. Psychiatric Annals. 02. 2009;39(2):71-77. X-1, X-2.
575 Gironda MW, Der-Martirosian C, Belin TR, et al. Predictors of depressive symptoms following mandibular fracture repair. J Oral Maxillofac Surg. 02. 2009;67(2):328-34. X-1, X-5. [pmid: 19138607].
576 Gizzi M, Zlotnick M, Cicerone K, et al. Vestibular disease and cognitive dysfunction: no evidence for a causal connection. J Head Trauma Rehabil. 09–10. 2003;18(5):398-407. X-1. [pmid: 12973270].
577 GJDA, Evans AE. Cyclic, low-dose total body irradiation for metastatic neuroblastoma. Int J Radiat Oncol Biol Phys. 12. 1983;9(12):1961-5. X-1, X-2, X-3, X-5. [pmid: 9463100].
578 Glasgow GP, Mill WB. Cobalt-60 total body irradiation dosimetry at 220 cm sourceaxis distance. International Journal of Radiation Oncology, Biology, Physics. 1980;6(6):773-777. X-1, X-2.
579 Glasgow GP, Mill WB, Phillips GL, et al. Comparative 60Co total body irradiation (220 cm SAD) and 25 MV total body irradiation (370 cm SAD) dosimetry. International Journal of Radiation Oncology, Biology, Physics. 1980;6(9):1243-1250. X-1, X-2.
580 Glassmire DM, Kinney DI, Greene RL, et al. Sensitivity and specificity of MMPI-2 neurologic correction factors: receiver operating characteristic analysis. Assessment. 09. 2003;10(3):299-309. X-1. [pmid: 14503653].
581 Glenn MB, O’Neil-Pirozzi T, Goldstein R, et al. Depression amongst outpatients with traumatic brain injury. Brain Inj. 09. 2001;15(9):811-8. X-5. [pmid: 11516349].
582 Glenn MB, Wroblewski B. The choice of antidepressants in depressed survivors of traumatic brain injury. Journal of Head Trauma Rehabilitation. 09. 1989;4(3):85-88. X-2, X-5.
583 Glezer A, Murray E, Price B, et al. Effective use of electroconvulsive therapy after craniofacial reconstructive surgery. The Journal of ECT. 09. 2009;25(3):208-209. X-5. [pmid: 19145209].
584 Gloulou F, Allouche M, Khelil MB, et al. Unusual suicides with band saws: Two case reports and a literature review. Forensic Science International. 2009;183(1–3):e7-e10. X-1, X-2, X-5. [pmid: 19019591].
585 Gluck JP, Harry F. Harlow and animal research: reflection on the ethical paradox. Ethics Behav. 1997;7(2):149-61. X-1, X-2. [pmid: 11655129].
586 Gnjidic Z, Kubat M, Malenica M, et al. Epidemiological, forensic, clinical, and imaging characteristics of head injuries acquired in the suicide attempt with captive bolt gun. Acta Neurochir (Wien). 12. 2002;144(12):1271-7. X-1, X-5. [pmid: 12478338].
587 Godano U, Serracchioli A, Servadei F, et al. Intracranial lesions of surgical interest in minor head injuries in paediatric patients. Childs Nerv Syst. 05. 1992;8(3):136-8. X-1, X-3. [pmid: 1611613].
588 Godfrey HP, Harnett MA, Knight RG, et al. Assessing distress in caregivers of people with a traumatic brain injury (TBI): a psychometric study of the Head Injury Behaviour Scale. Brain Inj. 05. 2003;17(5):427-35. X-1. [pmid: 12745714].
589 Godfrey JR. Toward optimal health: The experts discuss memory loss in aging women. Journal of Women’s Health. 2004;13(8):856-862. X-1.
590 Golden Z, Golden CJ. The differential impacts of Alzheimer’s dementia, head injury, and stroke on personality dysfunction. Int J Neurosci. 06. 2003;113(6):869-78. X-1. [pmid: 12775349].
591 Goldsmith MM 3rd, Fry TL. Simple technique for stabilizing depressed zygomatic arch fractures. Laryngoscope. 03. 1986;96(3):325-6. X-1. [pmid: 3512942].
592 Goldstein FC, Levin HS. Neurobehavioral outcome of traumatic brain injury in older adults: initial findings. Journal of Head Trauma Rehabilitation. 1995;10(1):57-73. X-2, X-4, X-5.
593 Goldstein FC, Levin HS, Goldman WP, et al. Cognitive and neurobehavioral functioning after mild versus moderate traumatic brain injury in older adults. J Int Neuropsychol Soc. 03. 2001;7(3):373-83. X-5. [pmid: 11311038].
594 Goldstein FC, Levin HS, Goldman WP, et al. Cognitive and behavioral sequelae of closed head injury in older adults according to their significant others. J Neuropsychiatry Clin Neurosci. Winter. 1999;11(1):38-44. X-5. [pmid: 9990554].
595 Gordon D. Depressed fractures and missile wounds of the skull. Nurs Mirror Midwives J. 02. 26. 1976;142(8):45-6. X-1. [pmid: 1045359].
596 Gordon N. Migraine, epilepsy, post-traumatic syndromes, and spreading depression. Dev Med Child Neurol. 10. 1989;31(5):682-6. X-1, X-2, X-4, X-5. [pmid: 2680693].
597 Gordon VL. Recovery from a head injury: a family process. Pediatr Nurs. 03–04. 1989;15(2):131-3. X-1, X-2, X-4, X-5. [pmid: 2495518].
598 Gordon WA, Cantor JB, Johanning E, et al. Cognitive impairment associated with toxigenic fungal exposure: a replication and extension of previous findings. Appl Neuropsychol. 2004;11(2):65-74. X-1. [pmid: 15477176].
599 Gordon WA, Haddad L, Brown M, et al. The sensitivity and specificity of self-reported symptoms in individuals with traumatic brain injury. Brain Inj. 01. 2000;14(1):21-33. X-1. [pmid: 10670659].
600 Gorji A, Scheller D, Straub H, et al. Spreading depression in human neocortical slices. Brain Res. 07. 6. 2001;906(1–2):74-83. X-1. [pmid: 11430863].
601 Gosciniski I, Kwiatkowski S, Polak J, et al. The Kluver-Bucy syndrome. Acta Neurochirurgica. 1997;139(4):303-306. X-1, X-5. [pmid: 9202769].
602 Gouick J, Gentleman D. The emotional and behavioural consequences of traumatic brain injury. Trauma. 2004;6(4):285-92. X-2.
603 Gourlay D, Lun KC, Liya G. Review of virtual reality treatment for mental health. Stud Health Technol Inform. 2001;84(Pt 1):820-4. X-1, X-2. [pmid: 11604849].
604 Grados MA, Vasa RA, Riddle MA, et al. New onset obsessive-compulsive symptoms in children and adolescents with severe traumatic brain injury. Depress Anxiety. 2008;25(5):398-407. X-1, X-3. [pmid: 17957806].
605 Grafman J, Schwab K, Warden D, et al. Frontal lobe injuries, violence, and aggression: a report of the Vietnam Head Injury Study. Neurology. 05. 1996;46(5):1231-8. X-1. [pmid: 8628458].
606 Grafman J, Vance SC, Weingartner H, et al. The effects of lateralized frontal lesions on mood regulation. Brain. 12. 1986;109(Pt 6):1127-48. X-1. [pmid: 3790971].
607 Graham CA, Gordon MW, Roy CW, et al. Long-term outcomes of major trauma without head injury in the West of Scotland: pilot case-control study. Eur J Emerg Med. 02. 2007;14(1):35-8. X-1, X-5. [pmid: 17198324].
608 Graham CJ, Kittredge D, Stuemky JH. Injuries associated with child safety seat misuse. Pediatr Emerg Care. 12. 1992;8(6):351-3. X-1, X-3. [pmid: 1454645].
609 Grande LA, Loeser JD, Ozuna J, et al. Complex regional pain syndrome as a stress response. Pain. 2004;110(1–2):495-498. X-1, X-2, X-5. [pmid: 15275803].
610 Granger CV, Divan N, Fiedler RC. Functional assessment scales. A study of persons after traumatic brain injury. Am J Phys Med Rehabil. 03–04. 1995;74(2):107-13. X-5. [pmid: 7710723].
611 Grant JR, Southall PE, Fowler DR, et al. Death in custody: a historical analysis. J Forensic Sci. 09. 2007;52(5):1177-81. X-1. [pmid: 17645746].
612 Gray LN, Kalimuthu R, Jayaram B, et al. A retrospective study of treatment of orbital floor fractures with the maxillary sinus approach. Br J Plast Surg. 01. 1985;38(1):113-5. X-1. [pmid: 3967107].
613 Green A, Felmingham K, Baguley IJ, et al. The clinical utility of the Beck Depression Inventory after traumatic brain injury. Brain Inj. 12. 2001;15(12):1021-8. X-1. [pmid: 11712948].
614 Green CR, Mihic AM, Nikkel SM, et al. Executive function deficits in children with fetal alcohol spectrum disorders (FASD) measured using the Cambridge Neuropsychological Tests Automated Battery (CANTAB). J Child Psychol Psychiatry. 06. 2009;50(6):688-97. X-3. [pmid: 19175817].
615 Green P, Flaro L. Word memory test performance in children. Child Neuropsychol. 09. 2003;9(3):189-207. X-1, X-3. [pmid: 13680409].
616 Green RC, Cupples LA, Kurz A, et al. Depression as a risk factor for Alzheimer disease: the MIRAGE Study. Arch Neurol. 05. 2003;60(5):753-9. X-1. [pmid: 12756140].
617 Greenes DS, Schutzman SA. Infants with isolated skull fracture: what are their clinical characteristics, and do they require hospitalization. Ann Emerg Med. 09. 1997;30(3):253-9. X-1, X-3. [pmid: 9287884].
618 Greenes DS, Schutzman SA. Occult intracranial injury in infants. Ann Emerg Med. 12. 1998;32(6):680-6. X-1, X-3. [pmid: 9832664].
619 Greenes DS, Schutzman SA. Clinical indicators of intracranial injury in head-injured infants. Pediatrics. 10. 1999;104(4 Pt 1):861-7. X-1, X-3. [pmid: 10506226].
620 Greenes DS, Schutzman SA. Clinical significance of scalp abnormalities in asymptomatic head-injured infants. Pediatr Emerg Care. 04. 2001;17(2):88-92. X-1, X-3. [pmid: 11334100].
621 Groom KN, Shaw TG, O’Connor ME, et al. Neurobehavioral symptoms and family functioning in traumatically brain-injured adults. Arch Clin Neuropsychol. 11. 1998;13(8):695-711. X-1. [pmid: 14590629].
622 Gross CG. ‘Psychosurgery’ in renaissance art. Trends Neurosci. 10. 1999;22(10):429-31. X-1, X-2. [pmid: 10481185].
623 Gross H, Kling A, Henry G, et al. Local cerebral glucose metabolism in patients with long-term behavioral and cognitive deficits following mild traumatic brain injury. J Neuropsychiatry Clin Neurosci. Summer. 1996;8(3):324-34. X-5. [pmid: 8854305].
624 Gualtieri CT, Evans RW. Stimulant treatment for the neurobehavioural sequelae of traumatic brain injury. Brain Inj. 10–12. 1988;2(4):273-90. X-1, X-4, X-5. [pmid: 3060211].
625 Gualtieri CT, Johnson LG. Reliability and validity of a computerized neurocognitive test battery, CNS Vital Signs. Arch Clin Neuropsychol. 10. 2006;21(7):623-43. X-1. [pmid: 17014981].
626 Gualtieri F, Manetti D, Romanelli MN, et al. Design and study of piracetam-like nootropics, controversial members of the problematic class of cognition-enhancing drugs. Current Pharmaceutical Design. 2002;8(2):125-138. X-2. [pmid: 11812254].
627 Guercio JM, Braunling-Mcmorrow D. Postacute neurobehavioral treatment: current perspectives on incidence, demographics, and contemporary delivery systems. Case Manager. 03–04. 2004;15(2):66-9. X-1. [pmid: 15026771].
628 Guercio JM, McMorrow MJ. Proactive protocols for severe unwanted behavior after acquired brain injury. Case Manager. 01–02. 2002;13(1):55-8. X-1, X-2, X-4, X-5. [pmid: 11818909].
629 Guercio JM, Podolska-Schroeder H, Rehfeldt RA. Using stimulus equivalence technology to teach emotion recognition to adults with acquired brain injury. Brain Inj. 06. 2004;18(6):593-601. X-1, X-5. [pmid: 15204339].
630 Guerreiro DF, Navarro R, Silva M, et al. Psychosis secondary to traumatic brain injury. Brain Injury. 04. 2009;23(4):358-361. X-5. [pmid: 19274520].
631 Guetin S, Soua B, Voiriot G, et al. The effect of music therapy on mood and anxietydepression: an observational study in institutionalised patients with traumatic brain injury. Ann Phys Rehabil Med. 02. 2009;52(1):30-40. X-5. [pmid: 19027186].
632 Guilleminault C, Faull KF, Miles L, et al. Posttraumatic excessive daytime sleepiness: a review of 20 patients. Neurology. 12. 1983;33(12):1584-9. X-1, X-5. [pmid: 6685831].
633 Guilleminault C, Yuen KM, Gulevich MG, et al. Hypersomnia after head-neck trauma: a medicolegal dilemma. Neurology. 02. 8. 2000;54(3):653-9. X-1. [pmid: 10680799].
634 Gunn J. Social factors and epileptics in prison. Br J Psychiatry. 06. 1974;124(0):509-17. X-1. [pmid: 4854310].
635 Gunstad J, Suhr JA. “Expectation as etiology” versus “the good old days”: postconcussion syndrome symptom reporting in athletes, headache sufferers, and depressed individuals. J Int Neuropsychol Soc. 03. 2001;7(3):323-33. X-1. [pmid: 11311033].
636 Gunstad J, Suhr JA. Perception of illness: nonspecificity of postconcussion syndrome symptom expectation. J Int Neuropsychol Soc. 01. 2002;8(1):37-47. X-1. [pmid: 11843073].
637 Gunstad J, Suhr JA. Cognitive factors in Postconcussion Syndrome symptom report. Arch Clin Neuropsychol. 04. 2004;19(3):391-405. X-1. [pmid: 15033224].
638 Gunter TD, Philibert R, Hollenbeck N. Medical and psychiatric problems among men and women in a community corrections residential setting. Behav Sci Law. 2009;27(5):695-711. X-1. [pmid: 19743513].
639 Gurr B, Coetzer BR. The effectiveness of cognitive-behavioural therapy for posttraumatic headaches. Brain Inj. 07. 2005;19(7):481-91. X-5. [pmid: 16134736].
640 Guskiewicz KM, Marshall SW, Bailes J, et al. Recurrent concussion and risk of depression in retired professional football players. Med Sci Sports Exerc. 06. 2007;39(6):903-9. X-6. [pmid: 17545878].
641 Guth PE. The effects of depression in head injured adults as related to educational level, gender, and activity level. Indiana University of Pennsylvania. 2000:133. X-5.
642 Guthkelch AN. Posttraumatic amnesia, post-concussional symptoms and accident neurosis. Eur Neurol. 1980;19(2):91-102. X-1. [pmid: 7389758].
643 Gutierrez PM, Brenner LA, Huggins JA. A preliminary investigation of suicidality in psychiatrically hospitalized veterans with traumatic brain injury. Arch Suicide Res. 2008;12(4):336-43. X-5. [pmid: 18828036].
644 Gutierrez-Gonzalez R, Boto GR, Rivero-Garvia M, et al. Penetrating brain injury by drill bit. Clinical Neurology & Neurosurgery. 2008;110(2):207-210. X-1, X-2, X-5. [pmid: 17983703].
645 Haase GR. Diseases presenting as dementia. Contemp Neurol Ser. 1971;9:163-207. X-1. [pmid: 4268945].
646 Hadida A, Kapur N, Mackway-Jones K, et al. Comparing two different methods of identifying alcohol related problems in the emergency department: A real chance to intervene. Emergency Medicine Journal. 2001;18(2):112-115. X-1. [pmid: 11300181].
647 Hadley R. Dejerine-Roussy syndrome. Clinical Chiropractic. 06. 2004;7(2):79-83. X-5.
648 Hagedoorn M, Molleman E. Facial disfigurement in patients with head and neck cancer: the role of social self-efficacy. Health Psychol. 09. 2006;25(5):643-7. X-1. [pmid: 17014282].
649 Hahn YS, Fuchs S, Flannery AM, et al. Factors influencing posttraumatic seizures in children. Neurosurgery. 05. 1988;22(5):864-7. X-1, X-3. [pmid: 3380275].
650 Hahn YS, McLone DG. Risk factors in the outcome of children with minor head injury. Pediatr Neurosurg. 05–06. 1993;19(3):135-42. X-1, X-3. [pmid: 8499326].
651 Hakimian S, Cheng-Hakimian A, Anderson GD, et al. Rufinamide: A new anti-epileptic medication. Expert Opinion on. Pharmacotherapy. 2007;8(12):1931-1940. X-1.
652 Halbauer JD, Ashford JW, Zeitzer JM, et al. Neuropsychiatric diagnosis and management of chronic sequelae of war-related mild to moderate traumatic brain injury. Journal of Rehabilitation Research and Development. 2009;46(6):757-795. X-1, X-2. [pmid: 20104402].
653 Hall D, Riley J, Swann I. Can alcohol intoxication be excluded as the cause of confusion following head injury. Scottish Medical Journal. 2005;50(1):24-26. X-1. [pmid: 15792385].
654 Hall KM, Bushnik T, Lakisic-Kazazic B, et al. Assessing traumatic brain injury outcome measures for long-term follow-up of community-based individuals. Arch Phys Med Rehabil. 03. 2001;82(3):367-74. X-5. [pmid: 11245760].
655 Hall KM, Karzmark P, Stevens M, et al. Family stressors in traumatic brain injury: a twoyear follow-up. Arch Phys Med Rehabil. 08. 1994;75(8):876-84. X-1, X-4. [pmid: 8053794].
656 Hall MT, Howard MO. Nitrite inhalant abuse in antisocial youth: prevalence, patterns, and predictors. J Psychoactive Drugs. 06. 2009;41(2):135-43. X-1. [pmid: 19705675].
657 Hall T, Barrera RD, Randon M. Reversible memory loss following treatment with fluoxetine: A case study. Behavioral Interventions. 07–09. 2000;15(3):217-224. X-1, X-5.
658 Hallberg LR, Hallberg U, Johansson M, et al. Daily living with hyperacusis due to head injury 1 year after a treatment programme at the hearing clinic. Scand J Caring Sci. 12. 2005;19(4):410-8. X-1, X-5. [pmid: 16324067].
659 Hallenbeck CE, Fink SL, Grossman JS. Measurement of intellectual inefficiency. Psychol Rep. 10. 1965;17(2):339-49. X-1. [pmid: 5890812].
660 Halley MK, Silva PD, Foley J, et al. Loss of consciousness: when to perform computed tomography. Pediatr Crit Care Med. 05. 2004;5(3):230-3. X-1, X-3. [pmid: 15115559].
661 Ham LP, Andrasik F, Packard RC, et al. Psychopathology in individuals with posttraumatic headaches and other pain types. Cephalalgia. 04. 1994;14(2):118-26. discussion 78. X-1, X-5. [pmid: 8062349].
662 Hammell KR. Psychosocial outcome following severe closed head injury. Int J Rehabil Res. 12. 1994;17(4):319-32. X-5. [pmid: 7875925].
663 Hammell KR. Psychosocial outcome following spinal cord injury. Paraplegia. 11. 1994;32(11):771-9. X-1, X-5. [pmid: 7885720].
664 Hammond DC. Neurofeedback to improve physical balance, incontinence, and swallowing. Journal of Neurotherapy. 2005;9(1):27-36. X-1, X-5.
665 Hamrick SE, Miller SP, Newton NR, et al. Nucleated red blood cell counts: not associated with brain injury or outcome. Pediatr Neurol. 10. 2003;29(4):278-83. X-1, X-3, X-5. [pmid: 14643387].
666 Handel SF, Ovitt L, Spiro JR, et al. Affective disorder and personality change in a patient with traumatic brain injury. Psychosomatics. 2007;48(1):67-70. X-1, X-2. [pmid: 17209153].
667 Hanks RA, Temkin N, Machamer J, et al. Emotional and behavioral adjustment after traumatic brain injury. Arch Phys Med Rehabil. 09. 1999;80(9):991-7. X-1. [pmid: 10488997].
668 Hanlon RE, Demery JA, Kuczen C, et al. Effect of traumatic subarachnoid haemorrhage on neuropsychological profiles and vocational outcome following moderate or severe traumatic brain injury. Brain Inj. 04. 2005;19(4):257-62. X-1. [pmid: 15832871].
669 Harrick L, Krefting L, Johnston J, et al. Stability of functional outcomes following transitional living programme participation: 3-year follow-up. Brain Inj. 07. 1994;8(5):439-47. X-5. [pmid: 7951206].
670 Harris JK, Godfrey HP, Partridge FM, et al. Caregiver depression following traumatic brain injury (TBI): a consequence of adverse effects on family members. Brain Inj. 03. 2001;15(3):223-38. X-1. [pmid: 11260771].
671 Harrison-Felix CL, Whiteneck GG, Jha A, et al. Mortality over four decades after traumatic brain injury rehabilitation: a retrospective cohort study. Arch Phys Med Rehabil. 09. 2009;90(9):1506-13. X-1. [pmid: 19735778].
672 Hart T, O’Neil-Pirozzi TM, Williams KD, et al. Racial differences in caregiving patterns, caregiver emotional function, and sources of emotional support following traumatic brain injury. J Head Trauma Rehabil. 03–04. 2007;22(2):122-31. X-1. [pmid: 17414314].
673 Hart T, Sherer M, Whyte J, et al. Awareness of behavioral, cognitive, and physical deficits in acute traumatic brain injury. Arch Phys Med Rehabil. 09. 2004;85(9):1450-6. X-1. [pmid: 15375815].
674 Hart T, Whyte J, Polansky M, et al. Community outcomes following traumatic brain injury: impact of race and preinjury status. J Head Trauma Rehabil. 03–04. 2005;20(2):158-72. X-1. [pmid: 15803039].
675 Hart T, Whyte J, Polansky M, et al. Concordance of patient and family report of neurobehavioral symptoms at 1 year after traumatic brain injury. Arch Phys Med Rehabil. 02. 2003;84(2):204-13. X-1. [pmid: 12601651].
676 Hartings JA, Strong AJ, Fabricius M, et al. Spreading depolarizations and late secondary insults after traumatic brain injury. J Neurotrauma. 11. 2009;26(11):1857-66. X-1, X-5. [pmid: 19508156].
677 Hartwig S, Tsokos M, Byard RW. Black powder handgun deaths remain an uncommon event. Am J Forensic Med Pathol. 12. 2009;30(4):350-3. X-1, X-5. [pmid: 19901807].
678 Harvey AG, Bryant RA. Predictors of acute stress following mild traumatic brain injury. Brain Inj. 02. 1998;12(2):147-54. X-5. [pmid: 9492962].
679 Hassan N, Turner-Stokes L, Pierce K, et al. A completed audit cycle and integrated care pathway for the management of depression following brain injury in a rehabilitation setting. Clin Rehabil. 08. 2002;16(5):534-40. X-1, X-5. [pmid: 12194624].
680 Hassan NA, Kelany RS, Emara AM, et al. Pattern of craniofacial injuries in patients admitted to Tanta University Hospital--Egypt. J Forensic Leg Med. 01. 2010;17(1):26-32. X-1, X-5. [pmid: 20083047].
681 Hattori N, Huang SC, Wu HM, et al. Correlation of regional metabolic rates of glucose with glasgow coma scale after traumatic brain injury. J Nucl Med. 11. 2003;44(11):1709-16. X-1, X-5. [pmid: 14602850].
682 Haut SR, Shinnar S, Moshe SL. Seizure clustering: risks and outcomes. Epilepsia. 01. 2005;46(1):146-9. X-1. [pmid: 15660781].
683 Hawley CA. Reported problems and their resolution following mild, moderate and severe traumatic brain injury amongst children and adolescents in the UK. Brain Inj. 02. 2003;17(2):105-29. X-3. [pmid: 12519639].
684 Hawley CA, Maden A. Mentally disordered offenders with a history of previous head injury: are they more difficult to discharge. Brain Inj. 09. 2003;17(9):743-58. X-1. [pmid: 12850941].
685 Hayakawa F, Okumura A, Kato T, et al. Disorganized patterns: chronic-stage EEG abnormality of the late neonatal period following severely depressed EEG activities in early preterm infants. Neuropediatrics. 10. 1997;28(5):272-5. X-1, X-3. [pmid: 9413007].
686 Haydel MJ, Shembekar AD. Prediction of intracranial injury in children aged five years and older with loss of consciousness after minor head injury due to nontrivial mechanisms. Ann Emerg Med. 10. 2003;42(4):507-14. X-1, X-3. [pmid: 14520321].
687 Healy JF, Crudale AS. Computed tomographic evaluation of depressed skull fractures and associated intracranial injury. Comput Radiol. 11–12. 1982;6(6):323-30. X-1, X-5. [pmid: 7166029].
688 Heary RF, Hunt CD, Krieger AJ, et al. Nonsurgical treatment of compound depressed skull fractures. J Trauma. 09. 1993;35(3):441-7. X-1. [pmid: 8371305].
689 Heiskanen O, Marttila I, Valtonen S. Prognosis of depressed skull fracture. Acta Chir Scand. 1973;139(7):605-8. X-1. [pmid: 4203450].
690 Heitger MH, Jones RD, Macleod AD, et al. Impaired eye movements in post-concussion syndrome indicate suboptimal brain function beyond the influence of depression, malingering or intellectual ability. Brain. 10. 2009;132(Pt 10):2850-70. X-1. [pmid: 19617197].
691 Hekmatpanah J, Pannaraj P, Callans L. Head injury in abused children (review of 190 cases over 30 years). Journal of Neuroscience Nursing. 2002;34(1):14-9. X-3.
692 Hellawell DJ, Taylor R, Pentland B. Persisting symptoms and carers’ views of outcome after subarachnoid haemorrhage. Clin Rehabil. 08. 1999;13(4):333-40. X-1, X-5. [pmid: 10460121].
693 Henderson S. Epidemiology of dementia. Ann Med Interne (Paris). 06. 1998;149(4):181-6. X-1. [pmid: 11490544].
694 Henriksson TG. Close range blasts toward the maxillofacial region in attempted suicide. Scand J Plast Reconstr Surg Hand Surg. 1990;24(1):81-6. X-1, X-5. [pmid: 2389127].
695 Henry GK, Heilbronner RL, Mittenberg W, et al. Comparison of the MMPI-2 restructured Demoralization Scale, Depression Scale, and Malingered Mood Disorder Scale in identifying non-credible symptom reporting in personal injury litigants and disability claimants. Clin Neuropsychol. 01. 2009;23(1):153-66. X-1. [pmid: 18609325].
696 Henry JD, Phillips LH, Crawford JR, et al. Cognitive and psychosocial correlates of alexithymia following traumatic brain injury. Neuropsychologia. 2006;44(1):62-72. X-1. [pmid: 15896816].
697 Herman E, Gluszcz A. Observations on a peculiar post-traumatic vasomotor syndrome: livedo recemosa universalis, pyramidal and extrapyramidal symptoms, speech disorders, epileptic seizures and progressive dementia. A clinico-pathological study. J Neurol Sci. 11–12. 1967;5(3):405-16. X-1. [pmid: 6073210].
698 Hernesniemi J. Outcome following head injuries in the aged. Acta Neurochir (Wien). 1979;49(1–2):67-79. X-1. [pmid: 525464].
699 Herrmann M, Curio N, Petz T, et al. Coping with illness after brain diseases--a comparison between patients with malignant brain tumors, stroke, Parkinson’s disease and traumatic brain injury. Disabil Rehabil. 08. 15. 2000;22(12):539-46. X-1. [pmid: 11005743].
700 Hersh CB, Sokol MS, Pfeffer CR. Transient psychosis with fluoxetine. Journal of the American Academy of Child & Adolescent Psychiatry. 09. 1991;30(5):851-852. X-3, X-5. [pmid: 1938810].
701 Hershey AD, Powers SW, Bentti A, et al. Effectiveness of amitriptyline in the prophylactic management of childhood headaches. Headache. 2000;40(7):539-549. X-1, X-3. [pmid: 10940092].
702 Herskovits EH, Chen R. Integrating data-mining support into a brain-image database using open-source components. Adv Med Sci. 2008;53(2):172-81. X-1. [pmid: 18467275].
703 Hesdorffer DC, Lee P. Health, wealth, and culture as predominant factors in psychosocial morbidity. Epilepsy and Behavior. 2009;15(2 SUPPL 1):S36-S40. X-1. [pmid: 19286476].
704 Hesdorffer DC, Rauch SL, Tamminga CA. Long-term psychiatric outcomes following traumatic brain injury: a review of the literature. J Head Trauma Rehabil. 11–12. 2009;24(6):452-9. X-2. [pmid: 19940678].
705 Hibbard M, Cantor J. Evaluating the impact of a peer mentoring program for individuals with TBI and their families. Neurorehabilitation & Neural Repair. 2005;19(4):388-9. X-1, X-2.
706 Hibbard MR, Cantor J, Charatz H, et al. Peer support in the community: initial findings of a mentoring program for individuals with traumatic brain injury and their families. J Head Trauma Rehabil. 04. 2002;17(2):112-31. X-5. [pmid: 11909510].
707 Hibbard MR, Gordon WA, Flanagan S, et al. Sexual dysfunction after traumatic brain injury. NeuroRehabilitation. 2000;15(2):107-20. X-1. [pmid: 11455088].
708 Hill JJ 3rd, Mobo BH Jr, Cullen MR. Separating deployment-related traumatic brain injury and posttraumatic stress disorder in veterans: preliminary findings from the Veterans Affairs traumatic brain injury screening program. Am J Phys Med Rehabil. 08. 2009;88(8):605-14. X-1. [pmid: 19620825].
709 Hilsabeck RC, Thompson MD, Irby JW, et al. Partial cross-validation of the Wechsler Memory Scale-Revised (WMS-R) General Memory-Attention/Concentration Malingering Index in a nonlitigating sample. Arch Clin Neuropsychol. 01. 2003;18(1):71-9. X-1. [pmid: 14591479].
710 Hirashima Y, Shindo K, Endo S. Measurement of the area of the anterior horn of the right lateral ventricle for the diagnosis of brain atrophy by CT. Correlation with several ventricular indices. Neuroradiology. 1983;25(1):23-7. X-1. [pmid: 6856077].
711 Hirschenfang S, Silber M, Benton JG. Psychological appraisal of the brain injured. J Rehabil. 09–10. 1967;33(5):23-4. X-1, X-2, X-4, X-5. [pmid: 6073253].
712 Hitiris N, Mohanraj R, Norrie J, et al. Predictors of pharmacoresistant epilepsy. Epilepsy Res. 07. 2007;75(2–3):192-6. X-1. [pmid: 17628429].
713 Hobbs CJ. Skull fracture and the diagnosis of abuse. Arch Dis Child. 03. 1984;59(3):246-52. X-1, X-3. [pmid: 6712273].
714 Hobbs MS, Fairbairn AS, Acheson ED, et al. Study of disease associations from linked records. Br J Prev Soc Med. 09. 1976;30(3):141-50. X-1, X-5. [pmid: 974433].
715 Hodkinson HM. Psychological medicine. The elderly man. Br Med J. 04. 5. 1975;2(5961):23-5. X-1. [pmid: 1137773].
716 Hoffman J, Pagulayan K, Zawaideh N, et al. Pain after traumatic brain injury: predictors and correlates. Neurorehabilitation & Neural Repair. 2005;19(4):379. X-1.
717 Hoffman JM, Pagulayan KF, Zawaideh N, et al. Understanding pain after traumatic brain injury: impact on community participation. Am J Phys Med Rehabil. 12. 2007;86(12):962-9. X-1. [pmid: 18090437].
718 Hoffmann GT. Evaluation and management of linear and depressed skull fractures. Ariz Med. 02. 1968;25(2):175-85. X-1. [pmid: 5638810].
719 Holdeman TC. Review of Invisible wounds of war: Psychological and cognitive injuries, their consequences, and services to assist recovery. Psychiatric Services. 02. 2009;60(2):273. X-2.
720 Holden C. Psychosurgery: legitimate therapy or laundered lobotomy. Science. 03. 16. 1973;179(4078):1109-12. X-1. [pmid: 11660995].
721 Hollander E. Witches, pumpkins, and other frightful topics. CNS Spectrums. 10. 2007;12(10):730-731. X-1, X-2.
722 Hollister LE, Boutros N. Clinical use of CT and MR scans in psychiatric patients. J Psychiatry Neurosci. 11. 1991;16(4):194-8. X-1. [pmid: 1786261].
723 Hollister LE, Shah NN. Structural brain scanning in psychiatric patients: a further look. J Clin Psychiatry. 06. 1996;57(6):241-4. X-1. [pmid: 8666560].
724 Holloway M, Bye AM, Moran K. Non-accidental head injury in children. Med J Aust. 06. 20. 1994;160(12):786-9. X-1, X-3, X-5. [pmid: 8208195].
725 Holmes JF, Baier ME, Derlet RW. Failure of the Miller criteria to predict significant intracranial injury in patients with a Glasgow Coma Scale score of 14 after minor head trauma. Acad Emerg Med. 08. 1997;4(8):788-92. X-1. [pmid: 9262697].
726 Holmes KD, Matthews BL. Three-point alignment of zygoma fractures with miniplate fixation. Arch Otolaryngol Head Neck Surg. 08. 1989;115(8):961-3. X-1. [pmid: 2751855].
727 Holtzer R, Burright RG, Donovick PJ. Depression and brain injury history of psychiatric patients. Society for Neuroscience Abstracts [Meeting]. 1998. 1998;24(1–2):740. X-7.
728 Holtzer R, Burright RG, Lynn SJ, et al. Behavioural differences between psychiatric patients with confirmed versus non-confirmed traumatic brain injuries. Brain Inj. 11. 2000;14(11):959-73. X-5. [pmid: 11104136].
729 Hong HS, Cha JG, Paik SH, et al. High-resolution sonography for nasal fracture in children. AJR Am J Roentgenol. 01. 2007;188(1):W86-92. X-1, X-3, X-5. [pmid: 17179332].
730 Honkanen R, Visuri T. Blood alcohol levels in a series of injured patients with special reference to accident and type of injury. Ann Chir Gynaecol. 1976;65(4):287-94. X-1. [pmid: 970907].
731 Hoofien D, Barak O, Vakil E, et al. Symptom checklist-90 revised scores in persons with traumatic brain injury: affective reactions or neurobehavioral outcomes of the injury. Appl Neuropsychol. 2005;12(1):30-9. X-1. [pmid: 15788221].
732 Hoofien D, Sharoni L. Measuring unawareness of deficits among patients with traumatic brain injury: reliability and validity of the Patient Competency Rating Scale--Hebrew version. Isr J Psychiatry Relat Sci. 2006;43(4):296-305. X-1, X-5. [pmid: 17338451].
733 Hooshmand H, Beckner E, Radfar F. Technical and clinical aspects of topographic brain mapping. Clin Electroencephalogr. 10. 1989;20(4):235-47. X-1. [pmid: 2791313].
734 Hooshmand H, Maloney M. The role of EEG in the emergency room. Clin Electroencephalogr. 10. 1980;11(4):163-8. X-1. [pmid: 7449160].
735 Horinaka N, Yasumoto Y, Kumami K, et al. Evaluation of regional cerebral blood flow in chronic subdural hematoma. Keio J Med. 02. 2000;49(Suppl 1):A156-8. X-1. [pmid: 10750371].
736 Horneman G, Folkesson P, Sintonen H, et al. Health-related quality of life of adolescents and young adults 10 years after serious traumatic brain injury. Int J Rehabil Res. 09. 2005;28(3):245-9. X-3. [pmid: 16046918].
737 Horner MD, Ferguson PL, Selassie AW, et al. Patterns of alcohol use 1 year after traumatic brain injury: a population-based, epidemiological study. J Int Neuropsychol Soc. 05. 2005;11(3):322-30. X-6. [pmid: 15892908].
738 Horner MD, Selassie AW, Lineberry L, et al. Predictors of psychological symptoms 1 year after traumatic brain injury: a population-based, epidemiological study. J Head Trauma Rehabil. 03–04. 2008;23(2):74-83. X-1. [pmid: 18362761].
739 Horsfield SA, Rosse RB, Tomasino V, et al. Fluoxetine’s effects on cognitive performance in patients with traumatic brain injury. Int J Psychiatry Med. 2002;32(4):337-44. X-1, X-5. [pmid: 12779183].
740 Hou J-GG, Lai E. Previous traumatic brain injury may be a risk factor of mood disorders in Parkinson’s disease. Neurology. [Meeting]. 03. 11. 2008;70(11 Suppl 1):A438. X-7.
741 Howes H, Edwards S, Benton D. Male body image following acquired brain injury. Brain Inj. 02. 2005;19(2):135-47. X-1, X-5. [pmid: 15841757].
742 Howes HF, Edwards S, Benton D. Female body image following acquired brain injury. Brain Inj. 06. 2005;19(6):403-15. X-1, X-5. [pmid: 16101263].
743 Hubble JP, Cao T, Hassanein RE, et al. Risk factors for Parkinson’s disease. Neurology. 09. 1993;43(9):1693-7. X-1. [pmid: 8414014].
744 Huber M, Kirchler E, Karner M, et al. Delusional parasitosis and the dopamine transporter. A new insight of etiology. Med Hypotheses. 2007;68(6):1351-8. X-1. [pmid: 17134847].
745 Hubl D, Hauf M, van Swam C, et al. Hearing dysphasic voices. Lancet. 2007;370(9586). X-1.
746 Hudson P. Multishot firearm suicide. Examination of 58 cases. Am J Forensic Med Pathol. 09. 1981;2(3):239-42. X-1. [pmid: 7325134].
747 Huebner RA, Johnson K, Bennett CM, et al. Community participation and quality of life outcomes after adult traumatic brain injury. Am J Occup Ther. 03–04. 2003;57(2):177-85. X-5. [pmid: 12674309].
748 Hughes D, Lanche M, Naccari C, et al. Noteworthy briefs from the field. Primary Psychiatry. 06. 2008;15(6):19-21. X-1, X-2, X-3, X-5.
749 Hughes JR. Two forms of the 6/sec spike and wave complex. Electroencephalogr Clin Neurophysiol. 05. 1980;48(5):535-50. X-1. [pmid: 6153962].
750 Hughes LK. Simplified radiography of the zygomatic arches (the rat’s head view). Radiol Technol. 05–06. 1982;53(6):513-6. X-1, X-2, X-3. [pmid: 6927714].
751 Hull AM, Lowe T, Devlin M, et al. Psychological consequences of maxillofacial trauma: a preliminary study. Br J Oral Maxillofac Surg. 10. 2003;41(5):317-22. X-5. [pmid: 14581024].
752 Humphrey M, Christmas E. A comparison of neurological and psychiatric patients on a serial discrimination keyboard task. Br J Soc Clin Psychol. 02. 1972;11(1):82-4. X-1. [pmid: 5024664].
753 Hung KL, Liao HT, Huang JS. Rational management of simple depressed skull fractures in infants. J Neurosurg. 07. 2005;103(1 Suppl):69-72. X-1, X-3, X-5. [pmid: 16122008].
754 Huntley JS, Blain C, Hood S, et al. Improving detection of alcohol misuse in patients presenting to an accident and emergency department. Emerg Med J. 03. 2001;18(2):99-104. X-1. [pmid: 11300208].
755 Hurst RS, Hajos M, Raggenbass M, et al. A novel positive allosteric modulator of the a7 neuronal nicotinic acetylcholine receptor: In vitro and in vivo characterization. Journal of Neuroscience. 2005;25(17):4396-4405. X-1. [pmid: 15858066].
756 Husain MM. Emotional Lability (Pseudobulbar Affect) in General Psychiatry: An Introduction. American Journal of Geriatric Pharmacotherapy (AJGP). 10. 2005;3(SupplA):3. X-1, X-2, X-4, X-5.
757 Huschak G, Zur Nieden K, Stuttmann R, et al. Changes in monocytic expression of aminopeptidase N/CD13 after major trauma. Clin Exp Immunol. 12. 2003;134(3):491-6. X-1. [pmid: 14632756].
758 Hussain SA, Haut SR, Lipton RB, et al. Incidence of epilepsy in a racially diverse, community-dwelling, elderly cohort: results from the Einstein aging study. Epilepsy Res. 10. 2006;71(2–3):195-205. X-1. [pmid: 16870396].
759 Hutchison M, Mainwaring LM, Comper P, et al. Differential emotional responses of varsity athletes to concussion and musculoskeletal injuries. Clin J Sport Med. 01. 2009;19(1):13-9. X-1. [pmid: 19124978].
760 Hux K, Schneider T, Bennett K. Screening for traumatic brain injury. Brain Inj. 01. 2009;23(1):8-14. X-1. [pmid: 19096967].
761 Hwang K, Kita Y. Alloplastic template fixation of blow-out fracture. J Craniofac Surg. 07. 2002;13(4):510-2. X-1. [pmid: 12140413].
762 Hwang K, Lee SI. Reduction of zygomatic arch fracture using a towel clip. J Craniofac Surg. 09. 1999;10(5):439-41. X-1, X-5. [pmid: 10726515].
763 Hwang K, You SH, Kim SG, et al. Analysis of nasal bone fractures; a six-year study of 503 patients. J Craniofac Surg. 03. 2006;17(2):261-4. X-1. [pmid: 16633172].
764 Hybels RL, Weimert TA. Evaluation of frontal sinus fractures. Arch Otolaryngol. 05. 1979;105(5):275-6. X-1, X-5. [pmid: 435152].
765 Ietswaart M, Milders M, Crawford JR, et al. Longitudinal aspects of emotion recognition in patients with traumatic brain injury. Neuropsychologia. 01. 15. 2008;46(1):148-59. X-1. [pmid: 17915263].
766 Inaba K, Teixeira PG, David JS, et al. Computed tomographic brain density measurement as a predictor of elevated intracranial pressure in blunt head trauma. Am Surg. 10. 2007;73(10):1023-6. X-1, X-5. [pmid: 17983073].
767 Inao S, Kawai T, Kabeya R, et al. Relation between brain displacement and local cerebral blood flow in patients with chronic subdural haematoma. J Neurol Neurosurg Psychiatry. 12. 2001;71(6):741-6. X-1, X-5. [pmid: 11723193].
768 Ing E, Ing T, Ing S. The effect of a hockey visor and sports goggles on visual function. Can J Ophthalmol. 04. 2002;37(3):161-7. X-1, X-5. [pmid: 12083475].
769 Inglese-Bieber M, Slaby AE. Serum alcohol levels and the incidence of trauma. Curr Alcohol. 1981;8:269-82. X-1. [pmid: 7343184].
770 Inoue Y, Izawa K, Kiryu S, et al. Bioluminescent evaluation of the therapeutic effects of total body irradiation in a murine hematological malignancy model. Exp Hematol. 12. 2008;36(12):1634-41. X-1, X-3. [pmid: 18951691].
771 Inzaghi MG, De Tanti A, Sozzi M. The effects of traumatic brain injury on patients and their families. A follow-up study. Eura Medicophys. 12. 2005;41(4):265-73. X-5. [pmid: 16474280].
772 Islam S, Hooi H, Hoffman GR. Presence of pre-existing psychological comorbidity in a group of facially injured patients: a preliminary investigation. J Oral Maxillofac Surg. 09. 2009;67(9):1889-94. X-1. [pmid: 19686926].
773 Iverson GL. Qualitative aspects of malingered memory deficits. Brain Inj. 01. 1995;9(1):35-40. X-1. [pmid: 7874094].
774 Iverson GL. Outcome from mild traumatic brain injury. Current Opinion in Psychiatry. 05. 2005;18(3):301-317. X-2. [pmid: 16639155].
775 Iverson GL. Misdiagnosis of the persistent postconcussion syndrome in patients with depression. Arch Clin Neuropsychol. 05. 2006;21(4):303-10. X-1. [pmid: 16797916].
776 Iverson GL, Gaetz M. Analysis of circadian heart patterns in persistent postconcussion syndrome research. Journal of Cognitive Rehabilitation. Spr. 2001;19(1):18-22. X-1, X-5.
777 Iverson GL, Green P. Measuring improvement or decline on the WAIS-R in inpatient psychiatry. Psychol Rep. 10. 2001;89(2):457-62. X-1. [pmid: 11783576].
778 Iverson GL, Lange RT. Examination of “postconcussion-like” symptoms in a healthy sample. Appl Neuropsychol. 2003;10(3):137-44. X-1, X-4. [pmid: 12890639].
779 Izci Y, Kayali H, Daneyemez M, et al. Comparison of clinical outcomes between anteroposterior and lateral penetrating craniocerebral gunshot wounds. Emerg Med J. 06. 2005;22(6):409-10. X-1, X-5. [pmid: 15911946].
780 Izci Y, Kayali H, Daneyemez M, et al. The clinical, radiological and surgical characteristics of supratentorial penetrating craniocerebral injuries: a retrospective clinical study. Tohoku J Exp Med. 09. 2003;201(1):39-46. X-1, X-5. [pmid: 14609259].
781 Jackson D, Turner-Stokes L, Murray J, et al. Validation of the Memory and Behavior Problems Checklist-1990R for use in acquired brain injury. Brain Inj. 07. 2007;21(8):817-24. X-1. [pmid: 17676439].
782 Jackson D, Turner-Stokes L, Murray J, et al. Acquired brain injury and dementia: a comparison of carer experiences. Brain Inj. 05. 2009;23(5):433-44. X-1. [pmid: 19301166].
783 Jackson WL Jr, Shorr AF. The yield of lumbar puncture to exclude nosocomial meningitis as aetiology for mental status changes in the medical intensive care unit. Anaesthesia & Intensive Care. 2006;34(1):21-24. X-1. [pmid: 16494144].
784 Jagannathan J, Okonkwo DO, Yeoh HK, et al. Long-term outcomes and prognostic factors in pediatric patients with severe traumatic brain injury and elevated intracranial pressure. J Neurosurg Pediatr. 10. 2008;2(4):240-9. X-1, X-3. [pmid: 18831656].
785 Jaggi JL, Obrist WD, Gennarelli TA, et al. Relationship of early cerebral blood flow and metabolism to outcome in acute head injury. J Neurosurg. 02. 1990;72(2):176-82. X-1. [pmid: 2295915].
786 Jamieson KG, Yelland JD. Depressed skull fractures in Australia. J Neurosurg. 08. 1972;37(2):150-5. X-1. [pmid: 5046083].
787 Jang YC, Kim YJ, Lee JW, et al. Face burns caused by flambe drinks. J Burn Care Res. 01–02. 2006;27(1):93-6. X-1, X-5. [pmid: 16566542].
788 Jani AA, Fierro M, Kiser S, et al. Hurricane Isabel-related mortality--virginia, 2003. J Public Health Manag Pract. 01–02. 2006;12(1):97-102. X-1, X-5. [pmid: 16340521].
789 Jansson B, Alstrom J. The relation between prognosis, symptoms and background factors in suspected schizophrenic insufficiencies in young people. Acta Psychiatr Scand Suppl. 1967;198:1-96. X-1. [pmid: 5239335].
790 Jarho L. Korsakoff-like amnesic syndrome in penetrating brain injury. A study of Finnish war veterans. Acta Neurol Scand Suppl. 1973;54:3-156. X-1. [pmid: 4521064].
791 Jelenko C. Letter: Centuries of compound depressed skull fracture management. JACEP. 04. 1976;5(4):278. X-1. [pmid: 778457].
792 Jelinski SE, Magnusson JE, Becker WJ. Factors associated with depression in patients referred to headache specialists. Neurology. 02. 13. 2007;68(7):489-95. X-5. [pmid: 17296914].
793 Jenkinson N, Ownsworth T, Shum D. Utility of the Canadian Occupational Performance Measure in community-based brain injury rehabilitation. Brain Inj. 11. 2007;21(12):1283-94. X-5. [pmid: 18236203].
794 Jennett B, Bond M. Assessment of outcome after severe brain damage. Lancet. 03. 1. 1975;1(7905):480-4. X-1, X-2, X-4, X-5. [pmid: 46957].
795 Jennett B, Miller JD. Infection after depressed fracture of skull. Implications for management of nonmissile injuries. J Neurosurg. 03. 1972;36(3):333-9. X-1. [pmid: 5059972].
796 Jennett B, Miller JD, Braakman R. Epilepsy after monmissile depressed skull fracture. J Neurosurg. 08. 1974;41(2):208-16. X-1. [pmid: 4210275].
797 Jennett WB. Mental symptoms after head injury. Nurs Times. 09. 15. 1967;63(37):1226-7. X-1, X-2, X-4, X-5. [pmid: 6068427].
798 Jerwood D, Price DJ, Georgiakodis FA. Predicting the potential for recovery within 24 hours of a head injury. Med Inform (Lond). 10–12. 1989;14(4):287-96. X-1. [pmid: 2622293].
799 Jinkins JR. “Papilledema”: neuroradiologic evaluation of optic disk protrusion with dynamic orbital CT. AJR Am J Roentgenol. 10. 1987;149(4):793-802. X-1. [pmid: 3498333].
800 John ER, Easton P, Prichep LS, et al. Standardized varimax descriptors of event related potentials: basic considerations. Brain Topogr. Winter. 1993;6(2):143-62. X-1. [pmid: 8123430].
801 Johns Hopkins University. Post traumatic brain injury (TBI) depression. 2008. 2010. 02. 8. Feb 5. X-7.
802 Johnson RE. Total body irradiation of chronic lymphocytic leukemia. Relationship between therapeutic response and prognosis. Cancer. 06. 1976;37(6):2691-6. X-1. [pmid: 949687].
803 Johnson SM, Johnson AC, Barton RG. Avalanche trauma and closed head injury: adding insult to injury. Wilderness Environ Med. Winter. 2001;12(4):244-7. X-1, X-5. [pmid: 11769920].
804 Jones C. Outcome following closed head injury. J Neurosurg Nurs. 08. 1981;13(4):178-83. X-1, X-2, X-5. [pmid: 6921219].
805 Jordan BD, Glass E, Ortega-Verdejo K. Assessment of neuropsychiatric symptoms in patients with traumatic brain injury. Neurology. [Meeting]. 04. 9. 2002;58(7 Supplement 3):A357. X-7.
806 Jorge R, Robinson RG. Mood disorders following traumatic brain injury. NeuroRehabilitation. 2002;17(4):311-324. X-1. [pmid: 12547979].
807 Jorge RE. Mood and anxiety disorders following traumatic brain injury: differences between military and nonmilitary injuries. Psychiatric Times. 06. 2008;25(7):60-1. 64. 6. X-1, X-2, X-4, X-5.
808 Jorge RE, Acion L, Starkstein SE, et al. Hippocampal volume and mood disorders after traumatic brain injury. Biol Psychiatry. 08. 15. 2007;62(4):332-8. X-5. [pmid: 17123480].
809 Jorge RE, Robinson RG, Starkstein SE, et al. Secondary mania following traumatic brain injury. Am J Psychiatry. 06. 1993;150(6):916-21. X-1. [pmid: 8494069].
810 Jorge RE, Starkstein SE. Pathophysiologic aspects of major depression following traumatic brain injury. Journal of Head Trauma Rehabilitation. 11–12. 2005;20(6):475-487. X-1, X-2, X-4, X-5. [pmid: 16304485].
811 Jorge RE, Starkstein SE, Arndt S, et al. Alcohol misuse and mood disorders following traumatic brain injury. Arch Gen Psychiatry. 07. 2005;62(7):742-9. X-1. [pmid: 15997015].
812 Jorm AF, Anstey KJ, Christensen H, et al. MRI hyperintensities and depressive symptoms in a community sample of individuals 60–64 years old. Am J Psychiatry. 04. 2005;162(4):699-705. X-1. [pmid: 15800141].
813 Joseph AB, Wroblewski B. Depression, antidepressants, and traumatic brain injury. Journal of Head Trauma Rehabilitation. 04. 1995;10(2):90-95. X-1, X-2, X-4, X-5. [pmid: 11660671].
814 Joseph AB, Wroblewski B. Update on pharmacology Depression, antidepressants, and traumatic brain injury. Journal of Head Trauma Rehabilitation. 04. 1995;10(2):90-5. X-2. [pmid: 11660671].
815 Josie KL, Peterson CC, Burant C, et al. Predicting family burden following childhood traumatic brain injury: a cumulative risk approach. J Head Trauma Rehabil. 11–12. 2008;23(6):357-68. X-3. [pmid: 19033828].
816 Judd D, Wilson SL. Psychotherapy with brain injury survivors: an investigation of the challenges encountered by clinicians and their modifications to therapeutic practice. Brain Inj. 06. 2005;19(6):437-49. X-1, X-5. [pmid: 16101266].
817 Kaelin DL, Cifu DX, Matthies B. Methylphenidate effect on attention deficit in the acutely brain-injured adult. Arch Phys Med Rehabil. 01. 1996;77(1):6-9. X-1, X-5. [pmid: 8554476].
818 Kaliski SZ. A comparison of risk factors for habitual violence in pre-trial subjects. Acta Psychiatr Scand Suppl. 2002;(412):58-61. X-1. [pmid: 12072129].
819 Kaminski TW, Cousino ES, Glutting JJ. Examining the relationship between purposeful heading in soccer and computerized neuropsychological test performance. Res Q Exerc Sport. 06. 2008;79(2):235-44. X-1, X-4, X-5. [pmid: 18664047].
820 Kanaka TS, Ramamurthi B. Management of depressed fractures of the skull. Neurol India. 01–03. 1967;15(1):10-1. X-1. [pmid: 6061471].
821 Kane FJ Jr. Carbon disulfide intoxication from overdosage of disulfiram. Am J Psychiatry. 11. 1970;127(5):690-4. X-1. [pmid: 4321579].
822 Kane NM, Cronan JJ, Dorfman GS, et al. Pediatric abdominal trauma: evaluation by computed tomography. Pediatrics. 07. 1988;82(1):11-5. X-1, X-3. [pmid: 3380592].
823 Kanetani K, Kimura M, Endo S. Therapeutic effects of milnacipran (serotonin noradrenalin reuptake inhibitor) on depression following mild and moderate traumatic brain injury. J Nippon Med Sch. 08. 2003;70(4):313-20. X-5.
824 Kant R, Coffey CE, Bogyi AM. Safety and efficacy of ECT in patients with head injury: a case series. J Neuropsychiatry Clin Neurosci. Winter. 1999;11(1):32-7. X-5. [pmid: 9990553].
825 Kant R, Smith-Seemiller L, Zeiler D. Treatment of aggression and irritability after head injury. Brain Inj. 08. 1998;12(8):661-6. X-5. [pmid: 9724837].
826 Kaplan A. Untreated vets: a “gathering storm” of PTSD/depression. Psychiatric Times. 10. Special Edition. 2008;25(12):12-3. X-1, X-2, X-5.
827 Kaplan C. Special Issues in Contraception: Caring for Women With Disabilities. Journal of Midwifery & Women’s Health. 2006;51(6):450-456. X-1, X-2.
828 Kaptigau WM, Ke L, Rosenfeld JV. Open depressed and penetrating skull fractures in Port Moresby General Hospital from 2003 to 2005. P N G Med J. 03–06. 2007;50(1–2):58-63. X-1. [pmid: 19354013].
829 Kapur N, Hutchinson P, Berry E, et al. Executive dysfunction in a case of transoralfrontal self-inflicted gunshot injury. Brain Injury. 2009;23(12):985-989. X-1, X-5. [pmid: 19831496].
830 Kasoff SS, Lansen TA, Holder D, et al. Aggressive physiologic monitoring of pediatric head trauma patients with elevated intracranial pressure. Pediatr Neurosci. 1988;14(5):241-9. X-1, X-3, X-5. [pmid: 3151702].
831 Kaufman Y, Cole P, Hollier L. Contemporary issues in facial gunshot wound management. J Craniofac Surg. 03. 2008;19(2):421-7. X-1. [pmid: 18362720].
832 Kausar R, Fife-Schaw C, Hampson S, et al. Head injury rehabilitation outcome in relation to the carers’ psychological distress. Asia Pacific Disability Rehabilitation Journal. 2009;20(1):99-111. X-1.
833 Kay GG. Guidelines for the psychological evaluation of air crew personnel. Occup Med. 04–06. 2002;17(2):227-45. iv. X-1, X-2. [pmid: 11872438].
834 Kellner MJ, Sher M, Stoopack JC. Extracapsular fibrous ankylosis of the mandible after open reduction of a zygomatic arch fracture: report of case. J Oral Surg. 09. 1979;37(9):665-8. X-1, X-5. [pmid: 288889].
835 Kelly DF, McArthur DL, Levin H, et al. Neurobehavioral and quality of life changes associated with growth hormone insufficiency after complicated mild, moderate, or severe traumatic brain injury. J Neurotrauma. 06. 2006;23(6):928-42. X-5. [pmid: 16774477].
836 Keshavan MS, Channabasavanna SM, Reddy GN. Post-traumatic psychiatric disturbances: patterns and predictors of outcome. Br J Psychiatry. 02. 1981;138:157-60. X-1, X-2, X-4, X-5. [pmid: 7260498].
837 Kessels RP, Ruis C, Kappelle LJ. The impact of self-reported depressive symptoms on memory function in neurological outpatients. Clin Neurol Neurosurg. 05. 2007;109(4):323-6. X-1, X-5. [pmid: 17250955].
838 Khan-Bourne N, Brown RG. Cognitive behaviour therapy for the treatment of depression in individuals with brain injury. Neuropsychological Rehabilitation. 2003;13(1–2):89-107. X-1, X-2, X-4, X-5. [pmid: 21854329].
839 Khateb A, Ammann J, Annoni JM, et al. Cognition-enhancing effects of donepezil in traumatic brain injury. Eur Neurol. 2005;54(1):39-45. X-5. [pmid: 16118495].
840 Khouzam HR. Depression: guidelines for effective primary care, part 1, diagnosis. Consultant. 07. 2007;47(8):757-60. 764. X-1.
841 Khouzam HR, Donnelly NJ. Remission of traumatic brain injury-induced compulsions during venlafaxine treatment. General Hospital Psychiatry. 01. 1998;20(1):62-63. X-1, X-5. [pmid: 9506256].
842 Kilani RA, Wetmore J. Neonatal subgaleal hematoma: presentation and outcome--radiological findings and factors associated with mortality. Am J Perinatol. 01. 2006;23(1):41-8. X-1, X-3, X-5. [pmid: 16450272].
843 Kile SJ, Bourgeois JA, Sugden S, et al. Drug therapies for the neurobehavioral sequelae of traumatic brain injury. Psychiatric Times. 03. 44. 2007;24(3):42-6. X-1, X-2, X-4, X-5.
844 Kim E, Humaran TJ. Divalproex in the management of neuropsychiatric complications of remote acquired brain injury. J Neuropsychiatry Clin Neurosci. Spring. 2002;14(2):202-5. X-1, X-5. [pmid: 11983796].
845 Kim E, Lauterbach EC, Reeve A, et al. Neuropsychiatric complications of traumatic brain injury: a critical review of the literature (a report by the ANPA Committee on Research). J Neuropsychiatry Clin Neurosci. Spring. 2007;19(2):106-27. X-2. [pmid: 17431056].
846 Kim H, Colantonio A. Intentional traumatic brain injury in Ontario, Canada. J Trauma. 12. 2008;65(6):1287-92. X-1. [pmid: 19077615].
847 Kim J-H, Ha K. Hypersensitive neurological response to lithium in a patient with organic bipolar disorder secondary to idiopathic basal ganglia calcification. Australian and New Zealand Journal of Psychiatry. 07. 2008;42(7):646. X-5. [pmid: 18612869].
848 Kim SH, Ahn KJ, Lee JM, et al. The usefulness of orbital lines in detecting blow-out fracture on plain radiography. Br J Radiol. 12. 2000;73(876):1265-9. X-1. [pmid: 11205669].
849 King NS. Emotional, neuropsychological, and organic factors: their use in the prediction of persisting postconcussion symptoms after moderate and mild head injuries. J Neurol Neurosurg Psychiatry. 07. 1996;61(1):75-81. X-1. [pmid: 8676166].
850 King NS. “Affect without recollection” in post-traumatic stress disorder where head injury causes organic amnesia for the event. Behavioural and Cognitive Psychotherapy. 2001;29(4):501-4. X-2, X-5.
851 King NS, Crawford S, Wenden FJ, et al. Early prediction of persisting post-concussion symptoms following mild and moderate head injuries. Br J Clin Psychol. 03. 1999;38(Pt 1):15-25. X-1. [pmid: 10212734].
852 King RB. Quality of life after stroke. University Of Illinois At Chicago. Health Sciences Center. 1990:169. X-1.
853 Kinoshita K, Kushi H, Hayashi N. Characteristics of parietal-parasagittal hemorrhage after mild or moderate traumatic brain injury. Acta Neurochir Suppl. 2003;86:343-6. X-1. [pmid: 14753465].
854 Kiraly MA, Kiraly SJ. Traumatic brain injury and delayed sequelae: A review - Traumatic brain injury and mild traumatic brain injury (concussion) are precursors to later-onset brain disorders, including early-onset dementia. ScientificWorldJournal. 2007;7:1768-1776. X-2. [pmid: 18040539].
855 Kirkpatrick JB. Head-in-motion contusions in young adults. Acta Neurochir Suppl (Wien). 1983;32:115-7. X-1. [pmid: 6581699].
856 Kirkwood M, Janusz J, Yeates KO, et al. Prevalence and correlates of depressive symptoms following traumatic brain injuries in children. Child Neuropsychol. 09. 2000;6(3):195-208. X-3. [pmid: 11402397].
857 Kishi Y, Robinson RG, Kosier JT. Suicidal ideation among patients during the rehabilitation period after life-threatening physical illness. J Nerv Ment Dis. 09. 2001;189(9):623-8. X-1, X-5. [pmid: 11580007].
858 Kishi Y, Robinson RG, Kosier JT. Suicidal ideation among patients with acute lifethreatening physical illness: patients with stroke, traumatic brain injury, myocardial infarction, and spinal cord injury. Psychosomatics. 09–10. 2001;42(5):382-90. X-1. [pmid: 11739904].
859 Kit KA, Mateer CA, Graves RE. The influence of memory beliefs in individuals with traumatic brain injury. Rehabilitation Psychology. 02. 2007;52(1):25-32. X-1, X-5.
860 Klein M, Houx PJ, Jolles J. Long-term persisting cognitive sequelae of traumatic brain injury and the effect of age. J Nerv Ment Dis. 08. 1996;184(8):459-67. X-5. [pmid: 8752074].
861 Klonoff PS, Lage GA. Suicide in patients with traumatic brain injury: Risk and prevention. Journal of Head Trauma Rehabilitation. 12. 1995;10(6):16-24. X-1, X-2, X-4, X-5.
862 Kluger Y, Jarosz D, Paul DB, et al. Diving injuries: a preventable catastrophe. J Trauma. 03. 1994;36(3):349-51. X-1, X-4, X-5. [pmid: 8145314].
863 Klun B, Jankovic. Stunning device as a suicide weapon. Acta Neurochir (Wien). 1989;97(3–4):111-3. X-1, X-5. [pmid: 2718801].
864 Knight RG, Devereux R, Godfrey HP. Caring for a family member with a traumatic brain injury. Brain Inj. 06. 1998;12(6):467-81. X-1. [pmid: 9638324].
865 Knottnerus AM, Turner-Stokes T, van de Weg FB, et al. Diagnosis and treatment of depression following acquired brain injury: a comparison of practice in the UK and the Netherlands. Clin Rehabil. 09. 2007;21(9):805-11. X-1. [pmid: 17875560].
866 Koc F, Yerdelen D, Koc Z. Multiple intracerebral hemorrhages following electroconvulsive therapy. Rivista di Neuroradiologia. 2005;18(5–6):589-591. X-1, X-5.
867 Koenigs M, Grafman J. Prefrontal asymmetry in depression? The long-term effect of unilateral brain lesions. Neurosci Lett. 08. 7. 2009;459(2):88-90. X-1. [pmid: 19422881].
868 Koenigs M, Huey ED, Calamia M, et al. Distinct regions of prefrontal cortex mediate resistance and vulnerability to depression. J Neurosci. 11. 19. 2008;28(47):12341-8. X-1. [pmid: 19020027].
869 Kohli A, Aggarwal NK. Firearm fatalities in Delhi, India. Leg Med (Tokyo). 10. 2006;8(5):264-8. X-1. [pmid: 16963304].
870 Kohlmeier RE, McMahan CA, DiMaio VJ. Suicide by firearms: a 15-year experience. Am J Forensic Med Pathol. 12. 2001;22(4):337-40. X-1. [pmid: 11764898].
871 Kokmen E. The EURODEM collaborative re-analysis of case-control studies of Alzheimer’s disease: implications for clinical research and practice. Int J Epidemiol. 1991;20(Suppl 2):S65-7. X-1, X-2. [pmid: 1917270].
872 Kokmen E, Beard CM, O’Brien PC, et al. Epidemiology of dementia in Rochester, Minnesota. Mayo Clin Proc. 03. 1996;71(3):275-82. X-1. [pmid: 8594286].
873 Kolakowsky-Hayner SA, Kreutzer JS. Pre-injury crime, substance abuse, and neurobehavioural functioning after traumatic brain injury. Brain Inj. 01. 2001;15(1):53-63. X-1. [pmid: 11201315].
874 Kompa S, Schareck B, Tympner J, et al. Comparison of emergency eye-wash products in burned porcine eyes. Graefes Arch Clin Exp Ophthalmol. 04. 2002;240(4):308-13. X-1, X-5. [pmid: 11981646].
875 Kopelman MD, Fleminger S. Experience and perspectives on the classification of organic mental disorders. Psychopathology. 03–06. 2002;35(2–3):76-81. X-1, X-2. [pmid: 12145488].
876 Korosec Jagodic H, Jagodic K, Podbregar M. Long-term outcome and quality of life of patients treated in surgical intensive care: a comparison between sepsis and trauma. Crit Care. 2006;10(5):R134. X-1. [pmid: 16978417].
877 Kortte KB, Wegener ST, Chwalisz K. Anosognosia and denial: their relationship to coping and depression in acquired brain injury. Rehabilitation Psychology. 2003;48(3):131-6. X-1, X-5.
878 Koson D, Robey A. Amnesia and competency to stand trial. Am J Psychiatry. 05. 1973;130(5):588-92. X-1. [pmid: 4699930].
879 Koukopoulos A, Sani G, Koukopoulos AE, et al. Endogenous and exogenous cyclicity and temperament in bipolar disorder: Review, new data and hypotheses. Journal of Affective Disorders. 2006;96(3):165-175. X-1, X-2. [pmid: 16997381].
880 Krakowski MI, Czobor P. Psychosocial risk factors associated with suicide attempts and violence among psychiatric inpatients. Psychiatr Serv. 12. 2004;55(12):1414-9. X-1. [pmid: 15572570].
881 Kraus MF. Neuropsychiatric sequelae of stroke and traumatic brain injury: The role of psychostimulants. International Journal of Psychiatry in Medicine. 1995;25(1):39-51. X-1, X-2. [pmid: 7649717].
882 Kreutzer JS, Gervasio AH, Camplair PS. Patient correlates of caregivers’ distress and family functioning after traumatic brain injury. Brain Inj. 04. 1994;8(3):211-30. X-1. [pmid: 8004080].
883 Kreutzer JS, Gervasio AH, Camplair PS. Primary caregivers’ psychological status and family functioning after traumatic brain injury. Brain Inj. 04. 1994;8(3):197-210. X-1. [pmid: 8004079].
884 Kreutzer JS, Harris JA, Myers SL, et al. Alcohol, brain injury, manslaughter, and suicide. Cognitive Rehabilitation. 07–08. 1990;8(4):14-18. X-1, X-2.
885 Kreutzer JS, Rapport LJ, Marwitz JH, et al. Caregivers’ well-being after traumatic brain injury: a multicenter prospective investigation. Arch Phys Med Rehabil. 06. 2009;90(6):939-46. X-1. [pmid: 19480869].
886 Kreutzer JS, Zasler ND. Psychosexual consequences of traumatic brain injury: methodology and preliminary findings. Brain Inj. 04–06. 1989;3(2):177-86. X-5. [pmid: 2730976].
887 Kriet JD, Stanley RB Jr, Grady MS. Self-inflicted submental and transoral gunshot wounds that produce nonfatal brain injuries: management and prognosis. J Neurosurg. 06. 2005;102(6):1029-32. X-1, X-5. [pmid: 16028761].
888 Krishnan B, El Sheikh MH. Dental forceps reduction of depressed zygomatic arch fractures. J Craniofac Surg. 05. 2008;19(3):782-4. X-1, X-5. [pmid: 18520399].
889 Kruit MC, MAvB, PAMH, et al. Migraine as a risk factor for subclinical brain lesions. JAMA. 2004;291:427-434. X-1. [pmid: 14747499].
890 Kublashvili M, Menabde G, Korsantia B, et al. Immune status during fracture of lower jaw. Georgian Med News. 02. 2006;(131):101-4. X-1, X-5. [pmid: 16575147].
891 Kucharska-Pietura K, David AS. The perception of emotional chimeric faces in patients with depression, mania and unilateral brain damage. Psychol Med. 05. 2003;33(4):739-45. X-1. [pmid: 12785476].
892 Kudsk KA, Mowatt-Larssen C, Bukar J, et al. Effect of recombinant human insulin-like growth factor I and early total parenteral nutrition on immune depression following severe head injury. Arch Surg. 01. 1994;129(1):66-70. discussion 70–1. X-1, X-5. [pmid: 8279942].
893 Kuipers P, Lancaster A. Developing a suicide prevention strategy based on the perspectives of people with brain injuries. J Head Trauma Rehabil. 12. 2000;15(6):1275-84. X-1, X-5. [pmid: 11056408].
894 Kumar CN, Andrade C, Murthy P. A randomized, double-blind comparison of lorazepam and chlordiazepoxide in patients with uncomplicated alcohol withdrawal. Journal of Studies on Alcohol and Drugs. 2009;70(3):467-474. X-1. [pmid: 19371497].
895 Kupers T. Technology and social control: some aspects of psychosurgery and psychotechnology. Edcentric. 12–01. 1974;33:18-20. X-1. [pmid: 11661407].
896 Kurihara K, Kim K. Open reduction and interfragment wire fixation of comminuted nasal fractures. Ann Plast Surg. 02. 1990;24(2):179-85. X-1. [pmid: 2316977].
897 Kurihara Y, Kawakita K, Douzono T, et al. A large-scale, long-term, prospective postmarketing surveillance of pitavastatin (LIVALOTablet)-LIVALO effectiveness and safety (LIVES) study. Japanese Pharmacology & Therapeutics. 2008;36(8):709-731. X-1.
898 Kurtz JE, Shealy SE, Putnam SH. Another look at paradoxical severity effects in head injury with the Personality Assessment Inventory. J Pers Assess. 02. 2007;88(1):66-73. X-1. [pmid: 17266416].
899 Kuruba R, Hattiangady B, Shetty AK. Hippocampal neurogenesis and neural stem cells in temporal lobe epilepsy. Epilepsy & Behavior. 2009;14(1 SUPPL 1):65-73. X-1, X-2. [pmid: 18796338].
900 Kyle JW, Jenkinson D. Letter: Depressed fracture in the newborn. Br Med J. 09. 29. 1973;3(5882):698. X-1. [pmid: 4742466].
901 La Vaque TJ, Rossiter T. The ethical use of placebo controls in clinical research: the Declaration of Helsinki. Appl Psychophysiol Biofeedback. 03. 2001;26(1):23-37. discussion 61–5. X-1, X-2, X-5. [pmid: 11387859].
902 Labauge P, Horzinski L, Ayrignac X, et al. Natural history of adult-onset eIF2B-related disorders: A multi-centric survey of 16 cases. Brain. 2009;132(8):2161-2169. X-1, X-5. [pmid: 19625339].
903 LaChapelle DL, Alfano DP. Revised neurobehavioral scales of the MMPI: sensitivity and specificity in traumatic brain injury. Appl Neuropsychol. 2005;12(3):143-50. X-1, X-5. [pmid: 16131341].
904 Ladurner G, Lorenzoni E. Electroencephalographic findings in the post-traumatic psychiatric syndrome. Electroencephalogr Clin Neurophysiol. 03. 1970;28(3):326. X-1. [pmid: 4190143].
905 LaHolt M, Rupright J. Insights into the medical management of brain injured veterans. Mo Med. 03–04. 2008;105(2):150-2. X-1, X-5. [pmid: 18453194].
906 Lahteenmaki PM, Chakrabarti S, Cornish JM, et al. Outcome of single fraction total body irradiation-conditioned stem cell transplantation in younger children with malignant disease: Comparison with a busulphan-cyclophosphamide regimen. Acta Oncologica. 2004;43(2):196-203. X-1, X-3, X-5. [pmid: 15163170].
907 Lakehead University Ontario Neurotrauma Foundation. Mindfulness-Based Cognitive Therapy Intervention to Treat Depression in Individuals with a Traumatic Brain Injury, ClinicalTrials.gov. [Internet]. 2008. 2010. 02. 8. Feb 5. X-7.
908 Lakits A, Prokesch R, Scholda C, et al. Orbital helical computed tomography in the diagnosis and management of eye trauma. Ophthalmology. 12. 1999;106(12):2330-5. X-1, X-5. [pmid: 10599667].
909 Lame EL, Redick TJ. A new radiographic technique for fractures of the orbit and maxilla. AJR Am J Roentgenol. 09. 1976;127(3):473-80. X-1. [pmid: 183536].
910 Landre N, Poppe CJ, Kiolbasa T. Prevalence of neuropathological indicators among acute psychiatric inpatients. J Nerv Ment Dis. 04. 2001;189(4):263-5. X-1. [pmid: 11339323].
911 Landy PJ. The post-traumatic syndrome in closed head injuries accident neurosis. Proc Aust Assoc Neurol. 1968;5(3):463-6. X-1. [pmid: 5709970].
912 Langefeld S, Kompa S, Redbrake C, et al. Aachen keratoprosthesis as temporary implant for combined vitreoretinal surgery and keratoplasty: report on 10 clinical applications. Graefes Arch Clin Exp Ophthalmol. 09. 2000;238(9):722-6. X-1, X-5. [pmid: 11045338].
913 Langeluddecke PM, Lucas SK. Quantitative measures of memory malingering on the Wechsler Memory Scale--Third edition in mild head injury litigants. Arch Clin Neuropsychol. 03. 2003;18(2):181-97. X-1. [pmid: 14591470].
914 Langfitt TW, Obrist WD, Gennarelli TA, et al. Correlation of cerebral blood flow with outcome in head injured patients. Ann Surg. 10. 1977;186(4):411-4. X-1, X-5. [pmid: 907387].
915 Langslow A. Observing at close quarters. Aust Nurs J. 10. 1997;5(4):32-3. X-1, X-2, X-5. [pmid: 9386397].
916 Lantz MS. Pathologic laughing and crying in multiple sclerosis. Clinical Geriatrics. 07. 2005;13(7):14-7. X-1, X-5.
917 LaPorta LD. Relief from migraine headache with aripiprazole treatment. Headache. 2007;47(6):922-926. X-1, X-5. [pmid: 17578547].
918 Large MM. Relationship between compensation claims for psychiatric injury and severity of physical injuries from motor vehicle accidents. Med J Aust. 08. 6. 2001;175(3):129-32. X-1. [pmid: 11548077].
919 Larrabee G. Detection of symptom exaggeration with the MMPI-2 in litigants with malingered neurocognitive dysfunction. Clin Neuropsychol. 02. 2003;17(1):54-68. X-1, X-5. [pmid: 12854011].
920 Larrabee GJ. Malingering Scales for the Continuous Recognition Memory Test and the Continuous Visual Memory Test. Clin Neuropsychol. 01. 2009;23(1):167-80. X-1. [pmid: 18609339].
921 Larsen KT Jr, Koziol DF. High yield criteria and emergency department skull radiography: two community hospitals’ experience. JACEP. 10. 1979;8(10):393-5. X-1, X-5. [pmid: 491326].
922 Larsen S, Harrington K, Hicks S, The LENS. (Low Energy Neurofeedback System): a clinical outcomes study on one hundred patients at Stone Mountain Center, New York. Journal of Neurotherapy. 2006;10(2–3):69-78. X-1, X-5.
923 Larsen S, Larsen R, Hammond DC, et al. The LENS neurofeedback with animals. Journal of Neurotherapy. 2006;10(2–3):89-104. X-1, X-3.
924 Larson MJ, Kaufman DA, Kellison IL, et al. Double jeopardy! The additive consequences of negative affect on performance-monitoring decrements following traumatic brain injury. Neuropsychology. 07. 2009;23(4):433-44. X-5. [pmid: 19586208].
925 Lasky JB, Epley KD, Karesh JW. Household objects as a cause of self-inflicted orbital apex syndrome. J Trauma. 03. 1997;42(3):555-8. X-1, X-5. [pmid: 9095130].
926 Lau IK, Davies DP. Non-accidental injury to children in Hong Kong: a 3-year hospital experience. Child Abuse Negl. 05–06. 1993;17(3):423-8. X-1. [pmid: 8330230].
927 Lauvrud C, Nonstad K, Palmstierna T. Occurrence of post traumatic stress symptoms and their relationship to professional quality of life (ProQoL) in nursing staff at a forensic psychiatric security unit: a cross-sectional study. Health Qual Life Outcomes. 2009;7:31. X-1. [pmid: 19371413].
928 Lawford BR, Mc DYR, Noble EP, et al. D2 dopamine receptor gene polymorphism: paroxetine and social functioning in posttraumatic stress disorder. Eur Neuropsychopharmacol. 10. 2003;13(5):313-20. X-1. [pmid: 12957328].
929 Leach LR, Frank RG, Bouman DE, et al. Family functioning, social support and depression after traumatic brain injury. Brain Inj. 10. 1994;8(7):599-606. X-5. [pmid: 7804296].
930 Leahy B, Suchy Y, Sweet JJ, et al. Behavioral Dyscontrol Scale deficits among traumatic brain injury patients, part I: Validation with nongeriatric patients. Clin Neuropsychol. 11. 2003;17(4):474-91. X-1, X-5. [pmid: 15168913].
931 Leathem JM, Body CM. Neuropsychological sequelae of head injury in a New Zealand adolescent sample. Brain Inj. 08. 1997;11(8):565-75. X-4, X-5. [pmid: 9251865].
932 Leddy JJ, Kozlowski K, Fung M, et al. Regulatory and autoregulatory physiological dysfunction as a primary characteristic of post concussion syndrome: Implications for treatment. NeuroRehabilitation. Special Issue: Sports and concussion. 2007;22(3):199-205. X-1, X-2, X-4, X-5.
933 Lee H, Kim S, Kim J, et al. Comparing effects of methylphenidate, sertraline and placebo on depressive symptoms and psychomotor function in patients with traumatic brain injury. International Journal of Neuropsychopharmacology. [Meeting]. 06. 2004;7(Suppl 2):S274. X-7.
934 Lee H, Kim SW, Kim JM, et al. Comparing effects of methylphenidate, sertraline and placebo on neuropsychiatric sequelae in patients with traumatic brain injury. Hum Psychopharmacol. 03. 2005;20(2):97-104. X-5. [pmid: 15641125].
935 Lee MA. Adolescent concussions - Management recommendations: A practical approach. Connecticut Medicine. 2006;70(6):377-380. X-1, X-2, X-3, X-5. [pmid: 16869469].
936 Lee TT, Ratzker PA, Galarza M, et al. Early combined management of frontal sinus and orbital and facial fractures. J Trauma. 04. 1998;44(4):665-9. X-1, X-2, X-3, X-5. [pmid: 9555839].
937 Lees-Haley PR, Brown RS. Neuropsychological complaint base rates of 170 personal injury claimants. Arch Clin Neuropsychol. 05. 1993;8(3):203-9. X-1. [pmid: 14589632].
938 Lees-Haley PR, Dunn JT. The ability of naive subjects to report symptoms of mild brain injury, post-traumatic stress disorder, major depression, and generalized anxiety disorder. J Clin Psychol. 03. 1994;50(2):252-6. X-1. [pmid: 8014250].
939 Lees-Haley PR, Williams CW, Zasler ND, et al. Response bias in plaintiffs’ histories. Brain Inj. 11. 1997;11(11):791-9. X-1. [pmid: 9354256].
940 Lefebvre H, Cloutier G, Josee Levert M. Perspectives of survivors of traumatic brain injury and their caregivers on long-term social integration. Brain Inj. 07. 2008;22(7–8):535-43. X-5. [pmid: 18568706].
941 LeFeuvre D, Taylor A, Peter JC. Compound depressed skull fractures involving a venous sinus. Surg Neurol. 08. 2004;62(2):121-5. discussion 125–6. X-1, X-5. [pmid: 15261501].
942 Lehman RK, Mink J. Altered Mental Status Clinical Pediatric Emergency Medicine. 2008;9(2):68-75. X-1, X-2.
943 Leon-Carrion J, De Serdio-Arias ML, Cabezas FM, et al. Neurobehavioural and cognitive profile of traumatic brain injury patients at risk for depression and suicide. Brain Inj. 02. 2001;15(2):175-81. X-5. [pmid: 11260767].
944 Leon-Carrion J, van Eeckhout P, del Dominguez-Morales MR, et al. The locked-in syndrome: a syndrome looking for a therapy. Brain Inj. 07. 2002;16(7):571-82. X-5. [pmid: 12119076].
945 Leonidas JC, Ting W, Binkiewicz A, et al. Mild head trauma in children: When is a roentgenogram Necessary. Pediatrics. 02. 1982;69(2):139-43. X-1, X-3, X-5. [pmid: 7058088].
946 Lesser IM, Miller BL, Boone KB, et al. Brain injury and cognitive function in late-onset psychotic depression. J Neuropsychiatry Clin Neurosci. Winter. 1991;3(1):33-40. X-1, X-5. [pmid: 7580170].
947 Levi L, Borovich B, Guilburd JN, et al. Wartime neurosurgical experience in Lebanon, 1982–85. II: Closed craniocerebral injuries. Isr J Med Sci. 10. 1990;26(10):555-8. X-1, X-5. [pmid: 2249929].
948 Levi L, Linn S, Revach M, et al. Head trauma in northern Israel: incidence and types. Neuroepidemiology. 1990;9(5):278-84. X-1. [pmid: 2087252].
949 Levine BA. Effects of depression and headache type on biofeedback for musclecontraction headaches. Behavioural Psychotherapy. 10. 1984;12(4):300-307. X-1, X-5.
950 Levine E, Degutis L, Pruzinsky T, et al. Quality of life and facial trauma: psychological and body image effects. Ann Plast Surg. 05. 2005;54(5):502-10. X-1. [pmid: 15838211].
951 Levine R, Lipson S, Devinsky O. Resolution of eating disorders after right temporal lesions. Epilepsy & Behavior. 2003;4(6):781-783. X-1, X-5. [pmid: 14698720].
952 Levine SH, Puchalski C. Pseudotumor cerebri associated with lithium therapy in two patients. Journal of Clinical Psychiatry. 1990;51(6):251-253. X-1, X-5. [pmid: 2347863].
953 Levitt Katz LE, Swami S, Abraham M, et al. Neuropsychiatric disorders at the presentation of type 2 diabetes mellitus in children. Pediatric Diabetes. 2005;6(2):84-89. X-1, X-3, X-5. [pmid: 15963035].
954 Lew HL, Vanderploeg RD, Moore DF, et al. Overlap of mild TBI and mental health conditions in returning OIF/OEF service members and veterans. J Rehabil Res Dev. 2008;45(3):xi-xvi. X-1, X-2, X-4, X-5. [pmid: 18629743].
955 Lewin W, Marshall TF, Roberts AH. Long-term outcome after severe head injury. Br Med J. 12. 15. 1979;2(6204):1533-8. X-1, X-4. [pmid: 119567].
956 Lewis DO, Pincus JH, Bard B, et al. Neuropsychiatric, psychoeducational, and family characteristics of 14 juveniles condemned to death in the United States. Am J Psychiatry. 05. 1988;145(5):584-9. X-1, X-3, X-5. [pmid: 3358463].
957 Lewis DO, Pincus JH, Feldman M, et al. Psychiatric, neurological, and psychoeducational characteristics of 15 death row inmates in the United States. Am J Psychiatry. 07. 1986;143(7):838-45. X-1, X-5. [pmid: 3717422].
958 Lewis DO, Shanok SS, Balla DA. Perinatal difficulties, head and face trauma, and child abuse in the medical histories of seriously delinquent children. Am J Psychiatry. 04. 1979;136(4A):419-23. X-1, X-3, X-5. [pmid: 570808].
959 Lewis P, Kopelman MD. Forgetting rates in neuropsychiatric disorders. J Neurol Neurosurg Psychiatry. 12. 1998;65(6):890-8. X-1, X-5. [pmid: 9854966].
960 Lewis SA. The relationship between depression and cognition in a population of military patients with traumatic brain injuries: a two-year longitudinal study. Howard University. 2001:70. X-7.
961 Li G, Baker SP, Fowler C, et al. Factors related to the presence of head injury in bicyclerelated pediatric trauma patients. J Trauma. 06. 1995;38(6):871-5. X-1, X-3, X-5. [pmid: 7602626].
962 Li JS, Cheng C, Jiang YH. Clinical analysis of 28 children suffering from intracranial hematoma and multiple injuries following traffic accidents. Chin J Traumatol. 12. 2004;7(6):378-9. X-1, X-3, X-5. [pmid: 15566697].
963 Light R, Asarnow R, Satz P, et al. Mild closed-head injury in children and adolescents: behavior problems and academic outcomes. J Consult Clin Psychol. 12. 1998;66(6):1023-9. X-3. [pmid: 9874916].
964 Lin CH, Wei FC, Chen CT, et al. Microsurgical tissue transplantation or replantation in patients with psychoneurological impairment. Plast Reconstr Surg. 10. 2001;108(5):1211-7. X-1, X-5. [pmid: 11604621].
965 Lin MR, Chiu WT, Chen YJ, et al. Longitudinal changes in the health-related quality of life during the first year after traumatic brain injury. Arch Phys Med Rehabil. 03. 2010;91(3):474-80. X-1. [pmid: 20298842].
966 Lindqvist G. Working as a full time psychiatrist in the neurosurgical department. Acta Psychiatr Scand Suppl. 1968;203:119-23. X-1. [pmid: 5248215].
967 Lindsay J, Laurin D, Verreault R, et al. Risk factors for Alzheimer’s disease: a prospective analysis from the Canadian Study of Health and Aging. Am J Epidemiol. 09. 1. 2002;156(5):445-53. X-1, X-5. [pmid: 12196314].
968 Lindsay J, McDowell I, Hill G, et al. The Canadian Study of Health and Aging: Risk factors for Alzheimer’s disease in Canada. Neurology. 1994;44(11):2073-2080. X-1, X-5. [pmid: 7969962].
969 Lindsay KW, McLatchie G, Jennett B. Serious head injury in sport. Br Med J. 09. 20. 1980;281(6243):789-91. X-1. [pmid: 7427450].
970 Liossi C, Wood RL. Gender as a moderator of cognitive and affective outcome after traumatic brain injury. J Neuropsychiatry Clin Neurosci. Winter. 2009;21(1):43-51. X-1. [pmid: 19359451].
971 Lipowski ZJ, Stewart AM. Illness as subjective experience. Int J Psychiatry Med. Spring. 1973;4(2):155-71. X-1. [pmid: 4716882].
972 Lippert-Gruner M, Kuchta J, Hellmich M, et al. Neurobehavioural deficits after severe traumatic brain injury (TBI). Brain Inj. 06. 2006;20(6):569-74. X-5. [pmid: 16754282].
973 Lipsey JR, Robinson RG, Pearlson GD, et al. Mood change following bilateral hemisphere brain injury. Br J Psychiatry. 09. 1983;143:266-73. X-5. [pmid: 6626839].
974 Lishman WA. Psychiatric disability after head injury: the significance of brain damage. Proc R Soc Med. 03. 1966;59(3):261-6. X-1. [pmid: 5909769].
975 Lishman WA. Brain damage in relation to psychiatric disability after head injury. Br J Psychiatry. 04. 1968;114(509):373-410. X-1. [pmid: 5656260].
976 Lishman WA. Psychiatric sequelae of head injuries: problems in diagnosis. Ir Med J. 06. 30. 1978;71(9):306-14. X-1. [pmid: 689862].
977 Liu JT, Tyan YS, Lee YK, et al. Emergency management of epidural haematoma through burr hole evacuation and drainage. A preliminary report. Acta Neurochir (Wien). 03. 2006;148(3):313-7. discussion 317. X-1, X-5. [pmid: 16437186].
978 Livingston DH, Lavery RF, Passannante MR, et al. Emergency department discharge of patients with a negative cranial computed tomography scan after minimal head injury. Ann Surg. 07. 2000;232(1):126-32. X-1, X-5. [pmid: 10862205].
979 Livingston MG, Brooks DN, Bond MR. Patient outcome in the year following severe head injury and relatives’ psychiatric and social functioning. J Neurol Neurosurg Psychiatry. 09. 1985;48(9):876-81. X-1. [pmid: 4045482].
980 Livingston MG, Brooks DN, Bond MR. Three months after severe head injury: psychiatric and social impact on relatives. J Neurol Neurosurg Psychiatry. 09. 1985;48(9):870-5. X-1, X-2, X-3, X-5. [pmid: 4045481].
981 Lloyd CJ, Alredy T, Lowry JC. Intranasal midazolam as an alternative to general anaesthesia in the management of children with oral and maxillofacial trauma. Br J Oral Maxillofac Surg. 12. 2000;38(6):593-595. X-1, X-3, X-5. [pmid: 11092772].
982 Lloyd DA, Carty H, Patterson M, et al. Predictive value of skull radiography for intracranial injury in children with blunt head injury. Lancet. 03. 22. 1997;349(9055):821-4. X-1, X-3, X-5. [pmid: 9121256].
983 Locke DE, Smigielski JS, Powell MR, et al. Effort issues in post-acute outpatient acquired brain injury rehabilitation seekers. NeuroRehabilitation. 2008;23(3):273-81. X-1. [pmid: 18560145].
984 Lof CM, Winiarski J, Giesecke A, et al. Health-related quality of life in adult survivors after paediatric allo-SCT. Bone Marrow Transplant. 03. 2009;43(6):461-8. X-1, X-4. [pmid: 18936733].
985 Loganovsky KN, Yuryev KL. EEG patterns in persons exposed to ionizing radiation as a result of the Chernobyl accident: part 1: conventional EEG analysis. J Neuropsychiatry Clin Neurosci. Fall. 2001;13(4):441-58. X-1. [pmid: 11748314].
986 Longman RS. Values for comparison of WAIS-III index scores with overall means. Psychol Assess. 09. 2004;16(3):323-5. X-1, X-5. [pmid: 15456387].
987 Longmore RB, McRae DA. Middle temporal veins - a potential hazard in the Gillies’ Operation. Br J Oral Surg. 06. 1981;19(2):129-31. X-1, X-5. [pmid: 6942878].
988 Lopes MA, Hototian SR, Bustamante SE, et al. Prevalence of cognitive and functional impairment in a community sample in Ribeirao Preto, Brazil. Int J Geriatr Psychiatry. 08. 2007;22(8):770-6. X-1, X-5. [pmid: 17173353].
989 Lopez OL, Becker JT, Klunk W, et al. Research evaluation and diagnosis of possible Alzheimer’s disease over the last two decades: II. Neurology. 12. 26. 2000;55(12):1863-9. X-1, X-5. [pmid: 11134386].
990 Lore JM Jr, Zingapan E. External traction for depressed facial fractures. N Y State J Med. 02. 15. 1972;72(4):490-2. X-1. [pmid: 4501385].
991 Loyd DW, Tsuang MT. A snake lady: post-concussion syndrome manifesting visual hallucinations of snakes. J Clin Psychiatry. 06. 1981;42(6):246-7. X-1, X-5. [pmid: 7240106].
992 Lubusko AA, Moore AD, Stambrook M, et al. Cognitive beliefs following severe traumatic brain injury: association with post-injury employment status. Brain Inj. 01. 1994;8(1):65-70. X-1, X-5. [pmid: 8124318].
993 Lugg DJ. Antarctic medicine, 1775–1975. II. Med J Aust. 08. 30. 1975;2(9):335-7. X-1. [pmid: 1186554].
994 Luis CA, Mittenberg W. Mood and anxiety disorders following pediatric traumatic brain injury: a prospective study. J Clin Exp Neuropsychol. 05. 2002;24(3):270-9. X-3. [pmid: 11992209].
995 Luis CA, Vanderploeg RD, Curtiss G. Predictors of postconcussion symptom complex in community dwelling male veterans. J Int Neuropsychol Soc. 11. 2003;9(7):1001-15. X-1. [pmid: 14738282].
996 Luiselli JK, Pace GM, Dunn EK. Antecedent analysis of therapeutic restraint in children and adolescents with acquired brain injury: a descriptive study of four cases. Brain Inj. 03. 2003;17(3):255-64. X-1, X-3, X-5. [pmid: 12623502].
997 Luxon LM, Harrison MJ. Chronic subdural haematoma. Q J Med. 01. 1979;48(189):43-53. X-1, X-2, X-5. [pmid: 482590].
998 Lyskowski JC, Menditto AA, Csernansky JG. Treatment of violent behavior in patients with Combined psychiatric illness and cognitive impairment: A case series. Mental Health Aspects of Developmental Disabilities. 2009;12(1):8-16. X-1, X-5.
999 MacGregor AJ, Shaffer RA, Dougherty AL, et al. Prevalence and psychological correlates of traumatic brain injury in operation iraqi freedom. J Head Trauma Rehabil. 01–02. 2010;25(1):1-8. X-1. [pmid: 20051901].
1000 Macgregor DM. Golf related head injuries in children. Emerg Med J. 11. 2002;19(6):576-7. X-1, X-3, X-5. [pmid: 12421796].
1001 Machamer J, Temkin N, Dikmen S. Significant other burden and factors related to it in traumatic brain injury. J Clin Exp Neuropsychol. 06. 2002;24(4):420-33. X-1. [pmid: 12187456].
1002 Mackenzie TB, Popkin MK. Suicide in the medical patient. International Journal of Psychiatry in Medicine. 1987;17(1):3-22. X-1, X-2. [pmid: 3294688].
1003 Mackersie RC, Shackford SR, Garfin SR, et al. Major skeletal injuries in the obtunded blunt trauma patient: a case for routine radiologic survey. J Trauma. 10. 1988;28(10):1450-4. X-1. [pmid: 3172304].
1004 Macmillan M. “I could see, and yet, mon, I could na’ see”: William Macewen, the agnosias, and brain surgery. Brain Cogn. 10. 2004;56(1):63-76. X-1, X-5. [pmid: 15380877].
1005 Macpherson BC, MacPherson P, Jennett B. CT evidence of intracranial contusion and haematoma in relation to the presence, site and type of skull fracture. Clin Radiol. 11. 1990;42(5):321-6. X-1. [pmid: 2245568].
1006 Macpherson P, Teasdale E. Can computed tomography be relied upon to detect skull fractures. Clin Radiol. 01. 1989;40(1):22-4. X-1, X-5. [pmid: 2920514].
1007 Madianos MG, Papaghelis M, Ioannovich J, et al. Psychiatric disorders in burn patients: a follow-up study. Psychother Psychosom. 01–02. 2001;70(1):30-7. X-1, X-5. [pmid: 11150936].
1008 Magee WL, Davidson JW. The effect of music therapy on mood states in neurological patients: a pilot study. J Music Ther. Spring. 2002;39(1):20-9. X-5. [pmid: 12015809].
1009 Maguen S, Lucenko BA, Reger MA, et al. The impact of reported direct and indirect killing on mental health symptoms in Iraq war veterans. Journal of Traumatic Stress. 02. 2010;23(1):86-90. X-1, X-5. [pmid: 20104592].
1010 Mainio A, Kyllonen T, Viilo K, et al. Traumatic brain injury, psychiatric disorders and suicide: a population-based study of suicide victims during the years 1988–2004 in Northern Finland. Brain Inj. 07. 2007;21(8):851-5. X-1. [pmid: 17676442].
1011 Maisano X, Carpentino J, Becker S, et al. Embryonic Stem Cell-Derived Neural Precursor Grafts for Treatment of Temporal Lobe Epilepsy. Neurotherapeutics. 2009;6(2):263-277. X-1, X-2. [pmid: 19332319].
1012 Makitie I, Pihlajamaki H. Fatal firearm injuries in Finland: a nationwide survey. Scand J Surg. 2002;91(4):328-31. X-1, X-5. [pmid: 12558080].
1013 Malaspina D, Goetz RR, Friedman JH, et al. Traumatic brain injury and schizophrenia in members of schizophrenia and bipolar disorder pedigrees. Am J Psychiatry. 03. 2001;158(3):440-6. X-1. [pmid: 11229986].
1014 Malec JF, Brown AW, Moessner AM. Personality factors and injury severity in the prediction of early and late traumatic brain injury outcomes. Rehabilitation Psychology. 2004;49(1):55-61. X-1.
1015 Malec JF, Machulda MM, Moessner AM. Differing problem perceptions of staff, survivors, and significant others after brain injury. Journal of Head Trauma Rehabilitation. 1997;12(3):1-13. X-1.
1016 Malec JF, Testa JA, Rush BK, et al. Self-assessment of impairment, impaired selfawareness, and depression after traumatic brain injury. J Head Trauma Rehabil. 05–06. 2007;22(3):156-66. X-1. [pmid: 17510591].
1017 Malkowicz D, Martinez D. Role of quantitative electroencephalography, neurotherapy, and neuroplasticity in recovery from neurological and psychiatric disorders. Journal of Neurotherapy. 2009;13(3):176-188. X-1, X-5.
1018 Mandal MK, Asthana HS, Tandon SC, et al. Role of cerebral hemispheres and regions in processing hemifacial expression of emotion: evidence from brain-damage. Int J Neurosci. 04. 1992;63(3–4):187-95. X-1, X-5. [pmid: 1304553].
1019 Mandal MK, Borod JC, Asthana HS, et al. Effects of lesion variables and emotion type on the perception of facial emotion. J Nerv Ment Dis. 10. 1999;187(10):603-9. X-1, X-5. [pmid: 10535653].
1020 Mandal MK, Mohanty A, Pandey R, et al. Emotion-specific processing deficit in focal brain-damaged patients. Int J Neurosci. 02. 1996;84(1–4):87-95. X-1, X-5. [pmid: 8707491].
1021 Mandelcorn J, Cullen NK, Bayley MT. A preliminary study of the efficacy of ondansetron in the treatment of ataxia, poor balance and incoordination from brain injury. Brain Injury. 2004;18(10):1025-1039. X-1, X-5. [pmid: 15370901].
1022 Manfredini M, Marliani AF. CT and plain X-ray examination of the skull in pure traumatic laceration of the brain. Neuroradiology. 1983;24(5):249-52. X-1. [pmid: 6835513].
1023 Mangano FT, Menendez JA, Smyth MD, et al. Pediatric neurosurgical injuries associated with all-terrain vehicle accidents: a 10-year experience at St. Louis Children’s Hospital. J Neurosurg. 07. 2006;105(1 Suppl):2-5. X-1, X-3. [pmid: 16871862].
1024 Mann JJ, Waternaux C, Haas GL, et al. Toward a clinical model of suicidal behavior in psychiatric patients. Am J Psychiatry. 02. 1999;156(2):181-9. X-1. [pmid: 9989552].
1025 Mannan A, Ghani S, Clarke A, et al. Psychosocial outcomes derived from an acid burned population in Bangladesh, and comparison with Western norms. Burns. 03. 2006;32(2):235-41. X-1, X-5. [pmid: 16448773].
1026 Mansoor O, Cayol M, Gachon P, et al. Albumin and fibrinogen syntheses increase while muscle protein synthesis decreases in head-injured patients. Am J Physiol. 11. 1997;273(5 Pt 1):E898-902. X-1. [pmid: 9374674].
1027 Mantyla M. Post-traumatic cerebral atrophy. A study on brain-injured veterans on the Finnish wars of 1939–40 and 1941–45. Ann Clin Res. 1981;13(32):1-47. X-7. [pmid: 7283378].
1028 Marbacher S, Andres RH, Fathi AR, et al. Primary reconstruction of open depressed skull fractures with titanium mesh. J Craniofac Surg. 03. 2008;19(2):490-5. X-1, X-5. [pmid: 18362730].
1029 Marcus DA. Disability and chronic posttraumatic headache. Headache. 02. 2003;43(2):117-21. X-1, X-5. [pmid: 12558765].
1030 Marinacci AA. Mental disorders associated with industrial head injury. IMS Ind Med Surg. 11–12. 1973;42(11):9-11. passim. X-1, X-2, X-4, X-5. [pmid: 4202275].
1031 Mark VH. A psychosurgeon’s case for psychosurgery. Psychol Today. 02. 1974;8(2):28+. X-1. [pmid: 11664315].
1032 Mark VH. Psychosurgery versus anti-psychiatry. Boston Univ Law Rev. 03. 1974;54(2):217-30. X-1. [pmid: 11661082].
1033 Markianos M, Seretis A, Kotsou S, et al. CSF neurotransmitter metabolites and shortterm outcome of patients in coma after head injury. Acta Neurol Scand. 08. 1992;86(2):190-3. X-1, X-5. [pmid: 1384260].
1034 Marmar CR. Mental health impact of Afghanistan and Iraq deployment: meeting the challenge of a new generation of veterans. Depress Anxiety. 2009;26(6):493-7. X-2. [pmid: 19484716].
1035 Marsh NV, Kersel DA, Havill JA, et al. Caregiver burden during the year following severe traumatic brain injury. J Clin Exp Neuropsychol. 06. 2002;24(4):434-47. X-1. [pmid: 12187457].
1036 Marsh NV, Kersel DA, Havill JH, et al. Caregiver burden at 1 year following severe traumatic brain injury. Brain Inj. 12. 1998;12(12):1045-59. X-6. [pmid: 9876864].
1037 Marsh NV, Kersel DA, Havill JH, et al. Caregiver burden at 6 months following severe traumatic brain injury. Brain Inj. 03. 1998;12(3):225-38. X-6. [pmid: 9547953].
1038 Marshall RS, Wallace T. The effect of combined individual and group treatment on functional communication in aphasia after acquired brain injury. Journal of Medical Speech-Language Pathology. 09. 2009;17(3):111-24. X-5.
1039 Martin C, Viguier D, Deloche G, et al. Subjective experience after traumatic brain injury. Brain Inj. 11. 2001;15(11):947-59. X-1. [pmid: 11689093].
1040 Martin CD. Ernest Hemingway: a psychological autopsy of a suicide. Psychiatry. Winter. 2006;69(4):351-61. X-1, X-2, X-5. [pmid: 17326729].
1041 Martin NA, Patwardhan RV, Alexander MJ, et al. Characterization of cerebral hemodynamic phases following severe head trauma: hypoperfusion, hyperemia, and vasospasm. J Neurosurg. 07. 1997;87(1):9-19. X-1. [pmid: 9202259].
1042 Martino C, Krysko M, Petrides G, et al. Cognitive tolerability of electroconvulsive therapy in a patient with a history of traumatic brain injury. Journal of ECT. 2008;24(1):92-95. X-5. [pmid: 18379342].
1043 Maruyama K, Okumura A, Hayakawa F, et al. Prognostic value of EEG depression in preterm infants for later development of cerebral palsy. Neuropediatrics. 06. 2002;33(3):133-7. X-1, X-3, X-5. [pmid: 12200742].
1044 Marwit SJ, Kaye PN. Measuring grief in caregivers of persons with acquired brain injury. Brain Inj. 12. 2006;20(13–14):1419-29. X-1, X-2, X-5. [pmid: 17378234].
1045 Marx BP, Brailey K, Proctor SP, et al. Association of time since deployment, combat intensity, and posttraumatic stress symptoms with neuropsychological outcomes following Iraq war deployment. Arch Gen Psychiatry. 09. 2009;66(9):996-1004. X-1. [pmid: 19736356].
1046 Masanic CA, Bayley MT, VanReekum R, et al. Open-label study of donepezil in traumatic brain injury. Arch Phys Med Rehabil. 07. 2001;82(7):896-901. X-5. [pmid: 11441374].
1047 Masel BE. Traumatic brain injury induced hypopituitarism: The need and hope of rehabilitation. Pituitary. 2005;8(3–4):263-266. X-1, X-2, X-5. [pmid: 16508707].
1048 Mason DJ. It’s all in my head. Am J Nurs. 07. 2003;103(7):61. X-2, X-5. [pmid: 12877128].
1049 Mason DJ. It’s all in my head: nurses should know the possible long-term consequences of head injury. American Journal of Nursing. 07. 2003;103(7):61. X-1, X-5. [pmid: 12877128].
1050 Mason S, Farrow TF, Fawbert D, et al. The development of a clinically useful tool for predicting the development of psychological disorder following injury. Br J Clin Psychol. 03. 2009;48(Pt 1):31-45. X-1. [pmid: 18799023].
1051 Massagli TL, Fann JR, Burington BE, et al. Psychiatric illness after mild traumatic brain injury in children. Arch Phys Med Rehabil. 09. 2004;85(9):1428-34. X-3. [pmid: 15375812].
1052 Masson F, Maurette P, Salmi LR, et al. Prevalence of impairments 5 years after a head injury, and their relationship with disabilities and outcome. Brain Inj. 07. 1996;10(7):487-97. X-1. [pmid: 8806009].
1053 Mastrapa TL, Fernandez LA, Alvarez MD, et al. Depressed skull fracture in Ping Pong: elevation with Medeva extractor. Childs Nerv Syst. 07. 2007;23(7):787-90. X-1, X-3, X-5. [pmid: 17486354].
1054 Mate-Kole CC, Conway J, Catayong K, et al. Validation of the revised quick cognitive screening test. Arch Phys Med Rehabil. 09. 2009;90(9):1469-77. X-1. [pmid: 19735773].
1055 Mate-Kole CC, Major A, Lenzer I, et al. Validation of the Quick Cognitive Screening Test. Arch Phys Med Rehabil. 08. 1994;75(8):867-75. X-1, X-5. [pmid: 8053793].
1056 Mateo MA, Glod CA, Hennen J, et al. Mild traumatic brain injury in psychiatric inpatients. J Neurosci Nurs. 02. 2005;37(1):28-33. X-6. [pmid: 15794442].
1057 Mather FJ, Tate RL, Hannan TJ. Post-traumatic stress disorder in children following road traffic accidents: a comparison of those with and without mild traumatic brain injury. Brain Inj. 12. 2003;17(12):1077-87. X-1, X-3, X-5. [pmid: 14555366].
1058 Mathias JL, Coats JL. Emotional and cognitive sequelae to mild traumatic brain injury. J Clin Exp Neuropsychol. 04. 1999;21(2):200-15. X-5. [pmid: 10425517].
1059 Mathiesen T, Kakarieka A, Edner G. Traumatic intracerebral lesions without extracerebral haematoma in 218 patients. Acta Neurochir (Wien). 1995;137(3–4):155-63. discussion 163. X-1, X-5. [pmid: 8789656].
1060 Matousek M, Roubicek J, Volavka J. The perspectives of research in psychiatric electroencephalography. I Methods. Electroencephalogr Clin Neurophysiol. 02. 1969;26(2):233. X-1.
1061 Matsuoka Y, Nishi D, Nakajima S, et al. Incidence and prediction of psychiatric morbidity after a motor vehicle accident in Japan: the Tachikawa Cohort of Motor Vehicle Accident Study. Crit Care Med. 01. 2008;36(1):74-80. X-1, X-5. [pmid: 18090377].
1062 Matthews CG, Klove H. MMPI performances in major motor, psychomotor and mixed seizure classifications of known and unknown etiology. Epilepsia. 03. 1968;9(1):43-53. X-1. [pmid: 4387029].
1063 Matuja WB. Epilepsy following non-missile head injury among African people in Dar es Salaam: a retrospective clinical analysis study. Afr J Med Med Sci. 06. 1990;19(2):89-92. X-1, X-5. [pmid: 2115733].
1064 Maughan R. Neurobehavioural nursing at Hartside. J Psychiatr Ment Health Nurs. 1994;1(1):52. X-1. [pmid: 7953804].
1065 Mauri M, Sinforiani E, Bono G, et al. Interaction between Apolipoprotein epsilon 4 and traumatic brain injury in patients with Alzheimer’s disease and Mild Cognitive Impairment. Funct Neurol. 10–12. 2006;21(4):223-8. X-1, X-5. [pmid: 17367583].
1066 Mauri MC, Colasanti A, Natoli A, et al. Psychiatric and neuropsychological sequelae of TBI: a case-control, longitudinal study. International Journal of Neuropsychopharmacology. [Meeting]. 07. 2008;11(Suppl 1):308. X-7.
1067 Mauri MC, Colasanti A, Paletta S, et al. Post traumatic brain injury major depression and primary major depression: psychopathological and neuropsychological profiles. European Neuropsychopharmacology. [Meeting]. 09. 2009;19(Suppl 3):S389. X-7.
1068 Maurin RK. Executive functioning in neuropsychiatric disorders: an overview. Semin Clin Neuropsychiatry. 01. 1999;4(1):2-4. X-1, X-2, X-4, X-5. [pmid: 10229787].
1069 Mavili ME, Canter HI, Tuncbilek G. Treatment of noncomminuted zygomatic fractures with percutaneous screw reduction and fixation. J Craniofac Surg. 01. 2007;18(1):67-73. X-1, X-5. [pmid: 17251839].
1070 Max JE, Castillo CS, Robin DA, et al. Posttraumatic stress symptomatology after childhood traumatic brain injury. J Nerv Ment Dis. 10. 1998;186(10):589-96. X-1, X-3. [pmid: 9788634].
1071 Max JE, Dunisch DL. Traumatic brain injury in a child psychiatry outpatient clinic: a controlled study. J Am Acad Child Adolesc Psychiatry. 03. 1997;36(3):404-11. X-1, X-3. [pmid: 9055522].
1072 Max JE, Koele SL, Smith WL Jr, et al. Psychiatric disorders in children and adolescents after severe traumatic brain injury: a controlled study. J Am Acad Child Adolesc Psychiatry. 08. 1998;37(8):832-40. X-3, X-5. [pmid: 9695445].
1073 Max JE, Lindgren SD, Knutson C, et al. Child and adolescent traumatic brain injury: psychiatric findings from a paediatric outpatient specialty clinic. Brain Inj. 10. 1997;11(10):699-711. X-3, X-5. [pmid: 9354246].
1074 Max JE, Lindgren SD, Knutson C, et al. Child and adolescent traumatic brain injury: correlates of disruptive behaviour disorders. Brain Inj. 01. 1998;12(1):41-52. X-1, X-3. [pmid: 9483336].
1075 Max JE, Lindgren SD, Robin DA, et al. Traumatic brain injury in children and adolescents: psychiatric disorders in the second three months. J Nerv Ment Dis. 06. 1997;185(6):394-401. X-3, X-5. [pmid: 9205426].
1076 Max JE, Roberts MA, Koele SL, et al. Cognitive outcome in children and adolescents following severe traumatic brain injury: influence of psychosocial, psychiatric, and injury-related variables. J Int Neuropsychol Soc. 01. 1999;5(1):58-68. X-3, X-5. [pmid: 9989025].
1077 Max JE, Robin DA, Lindgren SD, et al. Traumatic brain injury in children and adolescents: psychiatric disorders at two years. J Am Acad Child Adolesc Psychiatry. 09. 1997;36(9):1278-85. X-3, X-5. [pmid: 9291730].
1078 Max JE, Smith WL Jr, Sato Y, et al. Traumatic brain injury in children and adolescents: psychiatric disorders in the first three months. J Am Acad Child Adolesc Psychiatry. 01. 1997;36(1):94-102. X-3, X-5. [pmid: 9000786].
1079 Mayer L, Meuli M, Lips U, et al. The silent epidemic of falls from buildings: analysis of risk factors. Pediatr Surg Int. 09. 2006;22(9):743-8. X-1, X-3, X-5. [pmid: 16871397].
1080 Mayes SD, Calhoun SL. Similarities and differences in Wechsler Intelligence Scale for Children--Third Edition (WISC-III) profiles: support for subtest analysis in clinical referrals. Clin Neuropsychol. 12. 2004;18(4):559-72. X-1, X-3, X-5. [pmid: 15841957].
1081 Mayevsky A, Doron A, Manor T, et al. Cortical spreading depression recorded from the human brain using a multiparametric monitoring system. Brain Res. 11. 18. 1996;740(1–2):268-74. X-1, X-5. [pmid: 8973824].
1082 Mayevsky A, Doron A, Meilin S, et al. Brain viability and function analyzer: multiparametric real-time monitoring in neurosurgical patients. Acta Neurochir Suppl. 1999;75:63-6. X-1, X-5. [pmid: 10635379].
1083 Mayevsky A, Manor T, Meilin S, et al. Real-time multiparametric monitoring of the injured human cerebral cortex--a new approach. Acta Neurochir Suppl. 1998;71:78-81. X-1, X-5. [pmid: 9779150].
1084 Mayou R. Medicolegal aspects of road traffic accidents. J Psychosom Res. 08. 1995;39(6):789-98. X-2. [pmid: 8568736].
1085 Mayou R, Bryant B. Outcome in consecutive emergency department attenders following a road traffic accident. Br J Psychiatry. 12. 2001;179:528-34. X-1. [pmid: 11731357].
1086 Mayou R, Bryant B. Psychiatry of whiplash neck injury. Br J Psychiatry. 05. 2002;180:441-8. X-1, X-5. [pmid: 11983642].
1087 Mayou RA. Psychiatric consequences of motor vehicle accidents. Psychiatr Clin North Am. 03. 2002;25(1):27-41. vi. X-1, X-2, X-4, X-5. [pmid: 11912943].
1088 Mayou RA, Black J, Bryant B. Unconsciousness, amnesia and psychiatric symptoms following road traffic accident injury. Br J Psychiatry. 12. 2000;177:540-5. X-1. [pmid: 11102330].
1089 Mazzini L, Cossa FM, Angelino E, et al. Posttraumatic epilepsy: neuroradiologic and neuropsychological assessment of long-term outcome. Epilepsia. 04. 2003;44(4):569-74. X-4. [pmid: 12681007].
1090 McAllister TW. Evaluation and treatment of neurobehavioral complications of traumatic brain injury--have we made any progress. NeuroRehabilitation. 2002;17(4):263-4. X-1, X-2, X-4, X-5. [pmid: 12547975].
1091 McAvinue L, O’Keeffe F, McMackin D, et al. Impaired sustained attention and error awareness in traumatic brain injury: implications for insight. Neuropsychol Rehabil. 12. 2005;15(5):569-87. X-1, X-5. [pmid: 16381141].
1092 McBrinn J, Colin Wilson F, Caldwell S, et al. Emotional distress and awareness following acquired brain injury: an exploratory analysis. Brain Inj. 09. 2008;22(10):765-72. X-1. [pmid: 18787986].
1093 McCallum WC, Cummins B. The effects of brain lesions on the contingent negative variation in neurosurgical patients. Electroencephalogr Clin Neurophysiol. 11. 1973;35(5):449-56. X-1, X-5. [pmid: 4126450].
1094 McCann SJ, LeCouteur DG, Green AC, et al. The epidemiology of Parkinson’s disease in an Australian population. Neuroepidemiology. 1998;17(6):310-7. X-1, X-5. [pmid: 9778597].
1095 McCauley SR, Hannay HJ, Swank PR. Use of the Disability Rating Scale Recovery curve as a predictor of psychosocial outcome following closed-head injury. J Int Neuropsychol Soc. 05. 2001;7(4):457-67. X-1. [pmid: 11396548].
1096 McCauley SR, Pedroza C, Brown SA, et al. Confirmatory factor structure of the Center for Epidemiologic Studies-Depression scale (CES-D) in mild-to-moderate traumatic brain injury. Brain Inj. 05. 2006;20(5):519-27. X-1. [pmid: 16716998].
1097 McClain CJ, Twyman DL, Ott LG, et al. Serum and urine zinc response in head-injured patients. J Neurosurg. 02. 1986;64(2):224-30. X-1, X-5. [pmid: 3944632].
1098 McClelland RJ, Fenton GW, Rutherford W. The postconcussional syndrome revisited. J R Soc Med. 09. 1994;87(9):508-10. X-1, X-4, X-5. [pmid: 7932452].
1099 McCracken LM, Iverson GL. Predicting complaints of impaired cognitive functioning in patients with chronic pain. J Pain Symptom Manage. 05. 2001;21(5):392-6. X-1. [pmid: 11369160].
1100 McCrimmon S, Oddy M. Return to work following moderate-to-severe traumatic brain injury. Brain Inj. 09. 2006;20(10):1037-46. X-5. [pmid: 17060136].
1101 McCrory P, Meeuwisse W, Johnston K, et al. Consensus statement on concussion in sport - The 3rd International Conference on concussion in sport, held in Zurich, November 2008. Journal of Clinical Neuroscience. 2009;16(6):755-763. X-2. [pmid: 19410148].
1102 McCullagh S, Oucherlony D, Protzner A, et al. Prediction of neuropsychiatric outcome following mild trauma brain injury: an examination of the Glasgow Coma Scale. Brain Inj. 06. 2001;15(6):489-97. X-1. [pmid: 11394968].
1103 McDermott S, Moran R, Platt T, et al. Depression in adults with disabilities, in primary care. Disabil Rehabil. 02. 4. 2005;27(3):117-23. X-1. [pmid: 15823993].
1104 McDonald JV. The surgical management of severe open brain injuries with consideration of the long-term results. J Trauma. 10. 1980;20(10):842-7. X-1, X-5. [pmid: 7420494].
1105 McDonald S. Fostering tolerance toward survivors. British Journal of Neuroscience Nursing. 05. 2009;5(5):242. X-1, X-2.
1106 McDonald S, Flanagan S, Rollins J, et al. TASIT: A New Clinical Tool for Assessing Social Perception After Traumatic Brain Injury. Journal of Head Trauma Rehabilitation. 05–06. 2003;18(3):219-238. X-1, X-5. [pmid: 12802165].
1107 McDonald S, Tate R, Togher L, et al. Social skills treatment for people with severe, chronic acquired brain injuries: a multicenter trial. Arch Phys Med Rehabil. 09. 2008;89(9):1648-59. X-5. [pmid: 18760150].
1108 McEwen BS, Magarinos AM, Reagan LP. Structural plasticity and tianeptine: Cellular and molecular targets. European Psychiatry. 2002;17(SUPPL 3):318-330. X-1, X-2. [pmid: 15177088].
1109 McFadden JT. Straticulate decompression of depressed skull fractures. Surg Gynecol Obstet. 03. 1977;144(3):414-8. X-1. [pmid: 841460].
1110 McFarlane AC, Browne D, Bryant RA, et al. A longitudinal analysis of alcohol consumption and the risk of posttraumatic symptoms. J Affect Disord. 11. 2009;118(1–3):166-72. X-1. [pmid: 19230982].
1111 McGrath J. Cognitive impairment associated with post-traumatic stress disorder and minor head injury: a case report. Neuropsychological Rehabilitation. 1997;7(3):231-9. X-1, X-5.
1112 McGuire LM, Burright RG, Williams R, et al. Prevalence of traumatic brain injury in psychiatric and non-psychiatric subjects. Brain Inj. 03. 1998;12(3):207-14. X-1, X-5. [pmid: 9547951].
1113 McHenry M, Wilson R. The challenge of unintelligible speech following traumatic brain injury. Brain Injury. 1994;8(4):363-375. X-1, X-5. [pmid: 8081351].
1114 McKinlay A, Grace R, Horwood J, et al. Adolescent psychiatric symptoms following preschool childhood mild traumatic brain injury: evidence from a birth cohort. J Head Trauma Rehabil. 05–06. 2009;24(3):221-7. X-3. [pmid: 19461369].
1115 McLaughlin AM, Erdman J. Rehabilitation staff stress as it relates to patient acuity and diagnosis. Brain Inj. 01–02. 1992;6(1):59-64. X-1, X-2, X-5. [pmid: 1739853].
1116 McLay RN, Drake A, Santiago PN, et al. Major Depressive Disorder with Psychotic Features in an Aviator after Head Trauma. Aviation, Space, and Environmental Medicine. 02. 2004;75(2):175-179. X-5.
1117 McMahon MA, Noll RB, Michaud LJ, et al. Sibling adjustment to pediatric traumatic brain injury: a case-controlled pilot study. J Head Trauma Rehabil. 12. 2001;16(6):587-94. X-1, X-2, X-5. [pmid: 11732973].
1118 McMillan T, Robertson IH, Brock D, et al. Brief mindfulness training for attentional problems after traumatic brain injury: A randomised control treatment trial. Neuropsychological Rehabilitation: An International Journal. 2002;12(2):117-125. X-1.
1119 McMillan TM. Post-traumatic stress disorder and severe head injury. Br J Psychiatry. 09. 1991;159:431-3. X-1, X-5. [pmid: 1958957].
1120 McMillan TM. Post-traumatic stress disorder following minor and severe closed head injury: 10 single cases. Brain Inj. 10. 1996;10(10):749-58. X-1, X-5. [pmid: 8879665].
1121 McPherson KM, Kayes N, Weatherall M. A pilot study of self-regulation informed goal setting in people with traumatic brain injury. Clin Rehabil. 04. 2009;23(4):296-309. X-1, X-5. [pmid: 19293290].
1122 McQueen JD, Posey JB. Changes in intracranial pressure and brain hydration during acute ethanolism. Surg Neurol. 10. 1975;4(4):375-9. X-1. [pmid: 1237177].
1123 Meachen SJ, Hanks RA, Millis SR, et al. The reliability and validity of the brief symptom inventory-18 in persons with traumatic brain injury. Arch Phys Med Rehabil. 05. 2008;89(5):958-65. X-1. [pmid: 18452746].
1124 Meares S, Shores EA, Batchelor J, et al. The relationship of psychological and cognitive factors and opioids in the development of the postconcussion syndrome in general trauma patients with mild traumatic brain injury. J Int Neuropsychol Soc. 11. 2006;12(6):792-801. X-1. [pmid: 17064443].
1125 Meares S, Shores EA, Taylor AJ, et al. Mild traumatic brain injury does not predict acute postconcussion syndrome. J Neurol Neurosurg Psychiatry. 03. 2008;79(3):300-6. X-1. [pmid: 17702772].
1126 Mearns EA. Law and the physical control of the mind: experimentation in psychosurgery. Case West Reserve Law Rev. Spring. 1975;25(3):565-603. X-1. [pmid: 11661166].
1127 Meert KL, Long M, Kaplan J, et al. Alterations in immune function following head injury in children. Crit Care Med. 05. 1995;23(5):822-8. X-1, X-3, X-5. [pmid: 7736738].
1128 Mei H, Xing Y, Yang A, et al. Suprachoroidal hemorrhage during pars plana vitrectomy in traumatized eyes. Retina. 04. 2009;29(4):473-6. X-1, X-5. [pmid: 19174724].
1129 Meilijson SR, Kasher A, Elizur A. Language performance in chronic schizophrenia: a pragmatic approach. J Speech Lang Hear Res. 06. 2004;47(3):695-713. X-1, X-5. [pmid: 15212578].
1130 Mellman TA, David D, Bustamante V, et al. Predictors of post-traumatic stress disorder following severe injury. Depress Anxiety. 2001;14(4):226-31. X-1. [pmid: 11754130].
1131 Memorial Herman The Institute for Rehabilitation and Research (TIRR). Effectiveness of a Group Cognitive-Behavioral Intervention for Depression after TBI and Factors that Affect Response to Treatment. 2007 October 1, 2007. 2010. 02. 8. Feb 5. X-7.
1132 Mendelow AD, Campbell D, Tsementzis SA, et al. Prophylactic antimicrobial management of compound depressed skull fracture. J R Coll Surg Edinb. 03. 1983;28(2):80-3. X-1. [pmid: 6864611].
1133 Menzel JC. Depression in the elderly after traumatic brain injury: A systematic review. Brain Injury. 05. 2008;22(5):375-380. X-2. [pmid: 18415717].
1134 Merskey H, Woodforde JM. Psychiatric sequelae of minor head injury. Brain. 1972;95(3):521-8. X-1, X-5. [pmid: 4655278].
1135 Mervak TA. Physical and psychological factors in depression following closed head trauma. Dissertation Abstracts International. 1980;40(12-B, Pt 1). X-7.
1136 Metter EJ, Riege WH, Hanson WR, et al. Correlations of glucose metabolism and structural damage to language function in aphasia. Brain Lang. 03. 1984;21(2):187-207. X-1, X-5. [pmid: 6200176].
1137 Metz HS. Saccadic velocity measurements in strabismus. Trans Am Ophthalmol Soc. 1983;81:630-92. X-1, X-2, X-5. [pmid: 6676980].
1138 Meyer A. The anatomical facts and clinical varieties of traumatic insanity, 1904. J Neuropsychiatry Clin Neurosci. Summer. 2000;12(3):407-10. X-1, X-2, X-5. [pmid: 10956578].
1139 Meyer SE, Carlson GA, Wiggs EA, et al. A prospective high-risk study of the association among maternal negativity, apparent frontal lobe dysfunction, and the development of bipolar disorder. Dev Psychopathol. Spring. 2006;18(2):573-89. X-1, X-3, X-5. [pmid: 16600068].
1140 Meyers JE, Rohling ML. Validation of the Meyers Short Battery on mild TBI patients. Arch Clin Neuropsychol. 08. 2004;19(5):637-51. X-1. [pmid: 15271408].
1141 Meyler WJ, Bakker H, Kok JJ, et al. The effect of dantrolene sodium in relation to blood levels in spastic patients after prolonged administration. J Neurol Neurosurg Psychiatry. 04. 1981;44(4):334-9. X-1, X-5. [pmid: 7241161].
1142 Michaels AJ, Michaels CE, Smith JS, et al. Outcome from injury: general health, work status, and satisfaction 12 months after trauma. J Trauma. 05. 2000;48(5):841-8. discussion 848–50. X-1, X-5. [pmid: 10823527].
1143 Mickeviciene D, Schrader H, Nestvold K, et al. A controlled historical cohort study on the post-concussion syndrome. Eur J Neurol. 11. 2002;9(6):581-7. X-1. [pmid: 12453072].
1144 Mikawa S, Sharp FR, Kamii H, et al. Expression of c-fos and hsp70 mRNA after traumatic brain injury in transgenic mice overexpressing CuZn-superoxide dismutase. Brain Res Mol Brain Res. 11. 1995;33(2):288-94. X-1, X-3, X-5. [pmid: 8750888].
1145 Miller A. Pseudobulbar affect in multiple sclerosis: Toward the development of innovative therapeutic strategies. Journal of the Neurological Sciences. 2006;245(1–2):153-159. X-1, X-2, X-4, X-5. [pmid: 16674978].
1146 Miller CH, Quattrocchi KB, Frank EH, et al. Humoral and cellular immunity following severe head injury: review and current investigations. Neurol Res. 06. 1991;13(2):117-24. X-1, X-5. [pmid: 1682838].
1147 Miller EC, Derlet RW, Kinser D. Minor head trauma: Is computed tomography always necessary. Ann Emerg Med. 03. 1996;27(3):290-4. X-1, X-5. [pmid: 8599485].
1148 Miller EC, Holmes JF, Derlet RW. Utilizing clinical factors to reduce head CT scan ordering for minor head trauma patients. J Emerg Med. 07–08. 1997;15(4):453-7. X-1, X-5. [pmid: 9279694].
1149 Miller H. Mental after-effects of head injury. Proc R Soc Med. 03. 1966;59(3):257-61. X-1, X-2. [pmid: 5909768].
1150 Miller H, Cartlidge N. Simulation and malingering after injuries to the brain and spinal cord. Lancet. 03. 11. 1972;1(7750):580-5. X-1, X-2, X-4, X-5. [pmid: 4110060].
1151 Miller JD, Jennett WB. Complications of depressed skull fracture. Lancet. 11. 9. 1968;2(7576):991-5. X-1. [pmid: 4176375].
1152 Mimica N, Drmic S, Presecki P. Involuntary emotional expression disorder in Alzheimer’s disease - psychopharmacotherapy aspects. Psychiatr Danub. 09. 2009;21(3):425-8. X-1, X-2. [pmid: 19794369].
1153 Minderhoud JM, Boelens ME, Huizenga J, et al. Treatment of minor head injuries. Clin Neurol Neurosurg. 1980;82(2):127-40. X-1, X-2, X-5. [pmid: 6254711].
1154 Mintz MC, van Horn KR, Levine MJ. Developmental models of social cognition in assessing the role of family stress in relatives’ predictions following traumatic brain injury. Brain Inj. 02–03. 1995;9(2):173-86. X-1, X-5. [pmid: 7787837].
1155 Mirsal H, Yalug I, Tan D, et al. Delirium-associated disulfiram and ethanol interactions. Primary Care Companion to the Journal of Clinical Psychiatry. 2005;7(5):235-237. X-1, X-5.
1156 Mittal D, Jimerson N, Neely E. Persistent delirium secondary to lithium toxicity in a patient with dementia due to traumatic brain injury. Annals of Long Term Care. 2004;12(10):40-43. X-1, X-2.
1157 Mizuno T, Muranishi M, Torugun T, et al. Two Japanese CADASIL families exhibiting Notch3 mutation R75P not involving cysteine residue. Internal Medicine. 2008;47(23):2067-2072. X-1. [pmid: 19043263].
1158 Mlay SM. Epidural haematoma: a study of 71 cases. East Afr Med J. 09. 1989;66(9):598-602. X-1, X-4. [pmid: 2606049].
1159 Mlay SM. Delayed intracranial haematomas. East Afr Med J. 10. 1990;67(10):717-9. X-1, X-5. [pmid: 2282894].
1160 Mlay SM, Sayi EN. The management of depressed skull fractures in children at Muhimbili Medical Centre, Dar es Salaam, Tanzania. East Afr Med J. 05. 1993;70(5):291-3. X-1, X-3, X-5. [pmid: 8306906].
1161 Mogbo KI, Slovis TL, Canady AI, et al. Appropriate imaging in children with skull fractures and suspicion of abuse. Radiology. 08. 1998;208(2):521-4. X-1, X-3, X-5. [pmid: 9680586].
1162 Mokleby K, Blomhoff S, Malt UF, et al. Psychiatric comorbidity and hostility in patients with psychogenic nonepileptic seizures compared with somatoform disorders and healthy controls. Epilepsia. 02. 2002;43(2):193-8. X-1, X-5. [pmid: 11903468].
1163 Moldover JE, Goldberg KB, Prout MF. Depression After Traumatic Brain Injury: A Review of Evidence for Clinical Heterogeneity. Neuropsychology Review. 09. 2004;14(3):143-154. X-2. [pmid: 15673235].
1164 Mollica RF, Donelan K, Tor S, et al. The effect of trauma and confinement on functional health and mental health status of Cambodians living in Thailand-Cambodia border camps. JAMA. 08. 4. 1993;270(5):581-6. X-1. [pmid: 8331755].
1165 Mollica RF, Henderson DC, Tor S. Psychiatric effects of traumatic brain injury events in Cambodian survivors of mass violence. Br J Psychiatry. 10. 2002;181:339-47. X-1. [pmid: 12356662].
1166 Molteni E, Bianchi AM, Butti M, et al. Combined behavioral and EEG power analysis in DAI improve accuracy in the assessment of sustained attention deficit. Ann Biomed Eng. 07. 2008;36(7):1216-27. X-1, X-5. [pmid: 18452058].
1167 Monash University. The use of Motivational Interviewing and cognitive behavioural therapy to treat anxiety and/or depression following traumatic brain injury, Australian New Zealand Clinical Trials Registry. [Internet]. 2009. 2010. 02. 8. Feb 5. X-7.
1168 Mooney G, Speed J. Differential diagnosis in mild brain injury: understanding the role of non-organic conditions. NeuroRehabilitation. 1997;8(3):223-233. X-2.
1169 Moore AD, Stambrook M. Coping strategies and locus of control following traumatic brain injury: relationship to long-term outcome. Brain Inj. 01–02. 1992;6(1):89-94. X-1. [pmid: 1739858].
1170 Moore AD, Stambrook M. Coping following traumatic brain injury (TBI): derivation and validation of TBI sample Ways of Coping-Revised subscales. Canadian Journal of Rehabilitation. 1994;7(3):193-200. X-1.
1171 Moore AD, Stambrook M, Gill DD, et al. Differences in long-term quality of life in married and single traumatic brain injury patients. Canadian Journal of Rehabilitation. 1992;6(2):89-98. X-1.
1172 Moore AD, Stambrook M, Peters LC. Coping strategies and adjustment after closedhead injury: a cluster analytical approach. Brain Inj. 04–06. 1989;3(2):171-5. X-1. [pmid: 2730975].
1173 Moore BA, Donders J. Predictors of invalid neuropsychological test performance after traumatic brain injury. Brain Inj. 10. 2004;18(10):975-84. X-1, X-5. [pmid: 15370897].
1174 Moore C. Common psychiatric emergencies. Med J Aust. 06. 12. 1976;1(24):926-8. X-1, X-2, X-4, X-5. [pmid: 979750].
1175 Moran AJ. Problems of a head-injury patient. Med J Aust. 09. 30. 1972;2(14):782-3. X-1, X-2, X-5. [pmid: 4644637].
1176 Moran SG, McCarthy MC, Uddin DE, et al. Predictors of positive CT scans in the trauma patient with minor head injury. Am Surg. 07. 1994;60(7):533-5. discussion 535–6. X-1. [pmid: 8010569].
1177 Morley JB. Unruptured vertebro-basilar aneurysms. Med J Aust. 12. 2. 1967;2(23):1024-7. X-1. [pmid: 6066525].
1178 Morray JP, Tyler DC, Jones TK, et al. Coma scale for use in brain-injured children. Crit Care Med. 12. 1984;12(12):1018-20. X-1, X-5. [pmid: 6509997].
1179 Morris KC. Psychological distress in carers of head injured individuals: the provision of written information. Brain Inj. 03. 2001;15(3):239-54. X-1, X-2, X-5. [pmid: 11260772].
1180 Mortimer JA. Epidemiology of post-traumatic encephalopathy in boxers. Minn Med. 04. 1985;68(4):299-300. X-1, X-2, X-4, X-5. [pmid: 4010655].
1181 Mosdal C. Cranio-cerebral injuries from Slaughterer’s gun. Acta Neurochir (Wien). 1985;74(1–2):31-4. X-1, X-5. [pmid: 3976442].
1182 Moss-Herjanic B. Prolonged unconsciousness following electroconvulsive therapy. Am J Psychiatry. 07. 1967;124(1):74-6. X-1. [pmid: 4961006].
1183 Motherway JA, Verschueren P, Van der Perre G, et al. The mechanical properties of cranial bone: the effect of loading rate and cranial sampling position. J Biomech. 09. 18. 2009;42(13):2129-35. X-1, X-5. [pmid: 19640538].
1184 Mount Sinai School of Medicine U.S. Department of Education. Treatment of Post-TBI Depression Conditions, ClinicalTrials.gov. [Internet]. 2009. 2010. 02. 8. Feb 5. X-7.
1185 Mukherjee D, Reis JP, Heller W. Women living with traumatic brain injury: social isolation, emotional functioning and implications for psychotherapy. Women and Therapy. 2003;26(1–2):3-26. X-5.
1186 Mulhern S, McMillan TM. Knowledge and expectation of postconcussion symptoms in the general population. J Psychosom Res. 10. 2006;61(4):439-45. X-1. [pmid: 17011350].
1187 Muller JC, Buhrer C, Kiening KL, et al. Decreased soluble adhesion molecule L-selectin plasma concentrations after major trauma. J Trauma. 10. 1998;45(4):705-8. X-1, X-5. [pmid: 9783608].
1188 Muller RA, Rothermel RD, Behen ME, et al. Brain organization of language after early unilateral lesion: a PET study. Brain Lang. 05. 1998;62(3):422-51. X-1, X-3, X-5. [pmid: 9593617].
1189 Muller U, Murai T, Bauer-Wittmund T, et al. Paroxetine versus citalopram treatment of pathological crying after brain injury. Brain Inj. 10. 1999;13(10):805-11. X-5. [pmid: 10576464].
1190 Munday C. Premorbid personality, depression and ABI. re Learning Times. 2003;3:3. X-1.
1191 Muniu E, Katsivo MN, Mwaura LW, et al. Fatal non-transport injuries in Nairobi, Kenya. East Afr Med J. 06. 1994;71(6):346-9. X-1, X-5. [pmid: 7835251].
1192 Mupawose A, Katijah K, Naran V. Depression and pragmatics in adult patients with mild traumatic brain injury: An exploratory study. Journal of Psychology in Africa. Special Issue: Community psychology. 2007;17(1–2):111-114. X-5.
1193 Murai T, Fujimoto S. Rapid cycling bipolar disorder after left temporal polar damage. Brain Injury. 2003;17(4):355-358. X-1, X-5. [pmid: 12637187].
1194 Murshid WR. Role of skull radiography in the initial evaluation of minor head injury: a retrospective study. Acta Neurochir (Wien). 1994;129(1–2):11-4. X-1, X-5. [pmid: 7998489].
1195 Myers JE, Thompson ML, Ramushu S, et al. The nervous system effects of occupational exposure on workers in a South African manganese smelter. Neurotoxicology. 12. 2003;24(6):885-94. X-1. [pmid: 14637383].
1196 Myhrer T. Adverse psychological impact, glutamatergic dysfunction, and risk factors for Alzheimer’s disease. Neurosci Biobehav Rev. 1998;23(1):131-9. X-1. [pmid: 9861617].
1197 Mysiw WJ, Clinchot DM. Medications to enhance cognitive functioning. Physical Medicine & Rehabilitation Clinics of North America. 11. 1997;8(4):781-800. X-2.
1198 Mysiw WJ, Jackson RD. Tricyclic antidepressant therapy after traumatic brain injury. Journal of Head Trauma Rehabilitation. 1987;2(4):34-42. X-1, X-2.
1199 Nacajauskaite O, Endziniene M, Jureniene K, et al. The validity of post-concussion syndrome in children: a controlled historical cohort study. Brain Dev. 09. 2006;28(8):507-14. X-1, X-3. [pmid: 16682158].
1200 Nadas S, Gudinchet F, Capasso P, et al. Predisposing factors in obstetrical fractures. Skeletal Radiol. 1993;22(3):195-8. X-1, X-3, X-5. [pmid: 8480208].
1201 Nadas S, Reinberg O. Obstetric fractures. Eur J Pediatr Surg. 06. 1992;2(3):165-8. X-1, X-3, X-5. [pmid: 1498109].
1202 Nadell J, Kline DG. Primary reconstruction of depressed frontal skull fractures including those involving the sinus, orbit, and cribriform plate. J Neurosurg. 08. 1974;41(2):200-7. X-1. [pmid: 4210274].
1203 Nagib MG, Rockswold GL, Sherman RS, et al. Civilian gunshot wounds to the brain: prognosis and management. Neurosurgery. 05. 1986;18(5):533-7. X-1, X-2, X-5. [pmid: 3714000].
1204 Najdowski AC, Wallace MD, Ellsworth CL, et al. Functional analyses and treatment of precursor behavior. J Appl Behav Anal. Spring. 2008;41(1):97-105. X-1, X-4, X-5. [pmid: 18468282].
1205 Nakabayashi M, Suzaki S, Tomita H. Neural injury and recovery near cortical contusions: a clinical magnetic resonance spectroscopy study. J Neurosurg. 03. 2007;106(3):370-7. X-1, X-5. [pmid: 17367057].
1206 Nampiaparampil DE. Prevalence of chronic pain after traumatic brain injury: a systematic review. JAMA. 08. 13. 2008;300(6):711-9. X-2. [pmid: 18698069].
1207 Narushima K, Kosier JT, Robinson RG. A reappraisal of poststroke depression, intraand inter-hemispheric lesion location using meta-analysis. J Neuropsychiatry Clin Neurosci. Fall. 2003;15(4):422-30. X-1, X-2. [pmid: 14627768].
1208 Nasky KM, Hines NN, Simmer ED. The USS Cole bombing: analysis of pre-existing factors as predictors for development of post-traumatic stress or depressive disorders. Military Medicine. 07. 2009;174(7):689-694. X-1. [pmid: 19685839].
1209 Nasrallah H. Focus on lower risk of tardive dyskinesia with atypical antipsychotics. Annals of Clinical Psychiatry. 2006;18(1):57-62. X-1, X-2. [pmid: 16517454].
1210 Nathan PE, Gould CF, Zare NC, et al. A systems analytic model of diagnosis. VI. Improved diagnostic validity from median data. J Clin Psychol. 10. 1969;25(4):370-5. X-1. [pmid: 5809412].
1211 Nayak S, Wheeler BL, Shiflett SC, et al. Effect of music therapy on mood and social interaction among individuals with acute traumatic brain injury and stroke. Rehabilitation Psychology. 2000;45(3):274-83. X-1, X-5.
1212 Nelson CL, Winston DC. Detection of medical examiner cases from review of cremation requests. Am J Forensic Med Pathol. 06. 2006;27(2):103-5. X-1. [pmid: 16738425].
1213 Nelson EL, Melton LJ 3rd, Annegers JF, et al. Incidence of skull fractures in Olmsted County, Minnesota. Neurosurgery. 09. 1984;15(3):318-24. X-1. [pmid: 6332998].
1214 Nelson LA, Rhoades DA, Noonan C, et al. Traumatic brain injury and mental health among two American Indian populations. J Head Trauma Rehabil. 03–04. 2007;22(2):105-12. X-1. [pmid: 17414312].
1215 Nelson PT, Abner EL, Schmitt FA, et al. Modeling the association between 43 different clinical and pathological variables and the severity of cognitive impairment in a large autopsy cohort of elderly persons. Brain Pathology. 2010;20(1):66-79. X-1, X-5. [pmid: 19021630].
1216 Neville R. Pots and black kettles: a philosopher’s perspective on psychosurgery. Boston Univ Law Rev. 03. 1974;54(2):340-53. X-1. [pmid: 11661089].
1217 Newberg A, Alavi A, Reivich M. Determination of regional cerebral function with FDG-PET imaging in neuropsychiatric disorders. Seminars in Nuclear Medicine. 2002;32(1):13-34. X-1. [pmid: 11839066].
1218 Newburn G. Psychiatric disorders associated with traumatic brain injury: optimal treatment. CNS Drugs. 1998;9(6):441-456. X-2.
1219 Newburn G, Edwards R, Thomas H, et al. Moclobemide in the treatment of major depressive disorder (DSM-3) following traumatic brain injury. Brain Inj. 08. 1999;13(8):637-42. X-5. [pmid: 10901691].
1220 Newburn G, Newburn D. Selegiline in the management of apathy following traumatic brain injury. Brain Injury. 2005;19(2):149-154. X-1, X-5. [pmid: 15841758].
1221 Newlon PG, Greenberg RP, Enas GG, et al. Effects of therapeutic pentobarbital coma on multimodality evoked potentials recorded from severely head-injured patients. Neurosurgery. 06. 1983;12(6):613-9. X-1, X-5. [pmid: 6877543].
1222 Newnham WH. Some psychiatric conditions and the application of physiotherapy. Physiotherapy. 06. 1970;56(6):238-44. X-1, X-2, X-4, X-5. [pmid: 5447921].
1223 Nicholl J, LaFrance WC Jr. Neuropsychiatric sequelae of traumatic brain injury. Semin Neurol. 07. 2009;29(3):247-55. X-2. [pmid: 19551601].
1224 Nickels JL, Schneider WN, Dombovy ML, et al. Clinical use of amantadine in brain injury rehabilitation. Brain Inj. 11–12. 1994;8(8):709-18. X-5. [pmid: 7849690].
1225 Niemeier J, Kennedy R, McKinley W, et al. The Loss Inventory: preliminary reliability and validity data for a new measure of emotional and cognitive responses to disability. Disabil Rehabil. 05. 20. 2004;26(10):614-23. X-1, X-5. [pmid: 15204515].
1226 Niemeier JP. Unique aspects of women’s emotional responses to disability. Disabil Rehabil. 2008;30(3):166-73. X-1. [pmid: 17852249].
1227 Nieto Y, Patton N, Hawkins T, et al. Tacrolimus and mycophenolate mofetil after nonmyeloablative matched-sibling donor allogeneic stem-cell transplantations conditioned with fludarabine and low-dose total body irradiation. Biology of Blood & Marrow Transplantation. 2006;12(2):217-225. X-1, X-5. [pmid: 16443519].
1228 Nishimura N, Miyata Y. Cardiovascular changes in the terminal stage of disease. Resuscitation. 11. 1984;12(3):175-80. X-1, X-5. [pmid: 6096942].
1229 No authorship i. Mental and physical incompetency, Mental & Physical Disability Law Reporter. 11–12. 1985;9(6):412-413. X-1, X-2, X-5.
1230 Nordenram A, Freiberg N. Suicidal gunshot wounds resulting in severe maxillofacial injury. Int J Oral Surg. 1974;3(1):29-33. X-1. [pmid: 4211244].
1231 Nordlicht S. Facial disfigurement and psychiatric sequelae. N Y State J Med. 08. 1979;79(9):1382-4. X-1, X-2, X-4, X-5. [pmid: 291798].
1232 Novack TA, Banos JH, Brunner R, et al. Impact of early administration of sertraline on depressive symptoms in the first year after traumatic brain injury. J Neurotrauma. 11. 2009;26(11):1921-8. X-1. [pmid: 19929217].
1233 Novack TA, Bergquist TF, Bennett G, et al. Primary caregiver distress following severe head injury including commentary by Friss L. Journal of Head Trauma Rehabilitation. 1991;6(4):69-77. X-2, X-5.
1234 Nunery WR, Tao JP. Medial canthal open nasal fracture repair. Ophthal Plast Reconstr Surg. 07–08. 2008;24(4):276-9. X-1, X-5.
1235 Nybo T, Sainio M, Muller K. Middle age cognition and vocational outcome of childhood brain injury. Acta Neurol Scand. 11. 2005;112(5):338-42. X-5. [pmid: 16218918].
1236 Nystrom S. Slight head injury with severe sequelae--a problem of insurance medicine. Scand J Rehabil Med. 1972;4(2):73-6. X-1, X-2, X-4, X-5. [pmid: 4264803].
1237 Obajimi MO, Fatunde OJ, Ogunseyinde AO, et al. Computed tomography and childhood seizure disorder in Ibadan. West Afr J Med. 04–06. 2004;23(2):167-72. X-1, X-3. [pmid: 15287299].
1238 Obata T, Yamanaka Y, Inada T, et al. In vivo generation of hydroxyl radicals and MPTPinduced dopaminergic neurotoxicity in the striatum. Biogenic Amines. 2002;17(1):1-14. X-1.
1239 O’Brien KP. Relationship of psychosocial and physical dysfunction to emotional adjustment after traumatic brain injury. Journal of Clinical and Experimental Neuropsychology. [Meeting]. 1988;10(1):41-42. X-7.
1240 Obrist WD, Langfitt TW, Jaggi JL, et al. Cerebral blood flow and metabolism in comatose patients with acute head injury. Relationship to intracranial hypertension. J Neurosurg. 08. 1984;61(2):241-53. X-1. [pmid: 6737048].
1241 Ocana M, Jardine A, Ouchterlony D, et al. How mild is mild head injury? A neuropsychiatric study. Brain and Cognition. Special Issue: 9th Annual Rotman Research Inst Conference “Traumatic brain injury: Diagnosis, outcome, & rehabilitation”. March 24–26, 1999. 10. 2000;44(1):83-86. X-1.
1242 O’Carroll RE, Woodrow J, Maroun F. Psychosexual and psychosocial sequelae of closed head injury. Brain Inj. 07–09. 1991;5(3):303-13. X-5. [pmid: 1933079].
1243 Ochs L. The Low Energy Neurofeedback System (LENS): Theory, background, and introduction. Journal of Neurotherapy. 2006;10(2–3):5-39. X-1, X-2.
1244 O’Connell H, Clare AW. Nearly lethal suicide attempt--Implications for research and prevention. Irish Journal of Psychological Medicine. 12. 2004;21(4):131-133. X-1, X-5.
1245 O’Connor MJ. Cerebral metabolism in the acute severely head-injured patient: primary metabolic depression vs. ischemic hypoxia. Clin Neurosurg. 1982;29:146-61. X-1, X-2, X-4, X-5. [pmid: 6816497].
1246 Oddy M, Coughlan T, Tyerman A, et al. Social adjustment after closed head injury: a further follow-up seven years after injury. J Neurol Neurosurg Psychiatry. 06. 1985;48(6):564-8. X-1, X-4, X-5. [pmid: 4009193].
1247 Oddy M, Humphrey M, Uttley D. Stresses upon the relatives of head-injured patients. Br J Psychiatry. 12. 1978;133:507-13. X-1. [pmid: 737387].
1248 Oder W, Goldenberg G, Spatt J, et al. Behavioural and psychosocial sequelae of severe closed head injury and regional cerebral blood flow: a SPECT study. J Neurol Neurosurg Psychiatry. 06. 1992;55(6):475-80. X-5. [pmid: 1619415].
1249 O’Donnell ML, Creamer M, Bryant RA, et al. Posttraumatic disorders following injury: An empirical and methodological review. Clinical Psychology Review. 07. 2003;23(4):587-603. X-2. [pmid: 12788111].
1250 O’Donnell ML, Creamer M, Pattison P. Posttraumatic stress disorder and depression following trauma: Understanding comorbidity. American Journal of Psychiatry. 08. 2004;161(8):1390-1396. X-1. [pmid: 15285964].
1251 O’Donnell ML, Creamer M, Pattison P, et al. Psychiatric morbidity following injury. Am J Psychiatry. 03. 2004;161(3):507-14. X-1. [pmid: 14992977].
1252 O’Donnell ML, Creamer MC, Parslow R, et al. A predictive screening index for posttraumatic stress disorder and depression following traumatic injury. J Consult Clin Psychol. 12. 2008;76(6):923-32. X-1, X-5. [pmid: 19045961].
1253 Oh S. Clinical and experimental morphological study of depressed skull fracture. Acta Neurochir (Wien). 1983;68(1–2):111-21. X-1. [pmid: 6858726].
1254 Oh S, Ruedi M. Depressed skull fracture in skiing and its experimental study. Int J Sports Med. 08. 1982;3(3):169-73. X-1. [pmid: 7129727].
1255 Ohry A, Rattok J. The ‘hyperprosexia phenomenon’ in traumatic brain injured patients (a forgotten term for an old problem). Med Hypotheses. 08. 1990;32(4):269-72. X-1, X-2, X-5. [pmid: 2233416].
1256 Oka H, Kako M, Matsushima M, et al. Traumatic spreading depression syndrome. Review of a particular type of head injury in 37 patients. Brain. 06. 1977;100(2):287-98. X-1, X-3, X-5. [pmid: 406963].
1257 O’Keeffe FM, Dockree PM, Robertson IH. Poor insight in traumatic brain injury mediated by impaired error processing? Evidence from electrodermal activity. Brain Res Cogn Brain Res. 12. 2004;22(1):101-12. X-1, X-5. [pmid: 15561506].
1258 Olbrich HM, Nau HE, Lodemann E, et al. Evoked potential assessment of mental function during recovery from severe head injury. Surg Neurol. 08. 1986;26(2):112-8. X-1, X-5. [pmid: 3726736].
1259 Olson NR, Lehman RH. Cerebrospinal fluid otorrhea and the congenitally fixed stapes. Laryngoscope. 03. 1968;78(3):352-60. X-1. [pmid: 5642491].
1260 Ommaya AK, Salazar AM, Dannenberg AL, et al. Outcome after traumatic brain injury in the U.S. military medical system. J Trauma. 12. 1996;41(6):972-5. X-1. [pmid: 8970548].
1261 Opher S, Wills E. Workout with words - A poetry project in a GP surgery. British Journal of General Practice. 2004;54(499):156-157. X-1.
1262 Oppenheim-Gluckman H, Chambry J, Loisel Y, et al. How physicians caring for adult patients presenting with a chronic mental illness take into account the difficulties experienced by the children of those patients: preliminary study. Ann Phys Rehabil Med. 11. 2009;52(9):623-37. X-1, X-5. [pmid: 19854122].
1263 Oquendo MA, Echavarria G, Galfalvy HC, et al. Lower cortisol levels in depressed patients with comorbid post-traumatic stress disorder. Neuropsychopharmacology. 03. 2003;28(3):591-8. X-1. [pmid: 12629542].
1264 Oquendo MA, Friedman JH, Grunebaum MF, et al. Suicidal behavior and mild traumatic brain injury in major depression. J Nerv Ment Dis. 06. 2004;192(6):430-4. X-1. [pmid: 15167407].
1265 O’Riordan WD, Hubbell DV. Compound depressed skull fracture. JACEP. 02. 1976;5(2):123-4. X-1, X-3, X-5. [pmid: 933395].
1266 Osguthorpe NC. If your patient has contact lenses. Am J Nurs. 10. 1984;84(10):1255-6. X-1. [pmid: 6567453].
1267 O’Shanick GJ. Update on Antidepressants. Journal of Head Trauma Rehabilitation. 05–06. 2006;21(3):282-284. X-2. [pmid: 16717506].
1268 O’Shanick GJ, Scott R, Peterson LG. Psychiatric referral after head trauma. Psychiatr Med. 06. 1984;2(2):131-7. X-5. [pmid: 6571618].
1269 Otte A, Brandli M. Olfactory distress following mild traumatic head injnry: A SPECT follow-up. Journal of Vascular Investigation. 1998;4(4):207-209. X-1, X-2, X-5.
1270 Ouellet MC, Beaulieu-Bonneau S, Morin CM. Insomnia in patients with traumatic brain injury: frequency, characteristics, and risk factors. J Head Trauma Rehabil. 05–06. 2006;21(3):199-212. X-1. [pmid: 16717498].
1271 Ouellet MC, Morin CM. Subjective and objective measures of insomnia in the context of traumatic brain injury: a preliminary study. Sleep Med. 09. 2006;7(6):486-97. X-1, X-5. [pmid: 16934524].
1272 Ouellet MC, Morin CM, Lavoie A. Volunteer work and psychological health following traumatic brain injury. J Head Trauma Rehabil. 07–08. 2009;24(4):262-71. X-1. [pmid: 19625865].
1273 Ouellet MC, Sirois MJ, Lavoie A. Perceived mental health and needs for mental health services following trauma with and without brain injury. J Rehabil Med. 02. 2009;41(3):179-86. X-6. [pmid: 19229452].
1274 Owings JT, Bagley M, Gosselin R, et al. Effect of critical injury on plasma antithrombin activity: low antithrombin levels are associated with thromboembolic complications. J Trauma. 09. 1996;41(3):396-405. discussion 405–6. X-1. [pmid: 8810955].
1275 Ownsworth T. The Impact of Defensive Denial upon Adjustment Following Traumatic Brain Injury. Neuro-Psychoanalysis. 2005;7(1):83-94. X-5.
1276 Ownsworth T, Fleming J. The relative importance of metacognitive skills, emotional status, and executive function in psychosocial adjustment following acquired brain injury. J Head Trauma Rehabil. 07–08. 2005;20(4):315-32. X-1. [pmid: 16030439].
1277 Ownsworth T, Fleming J, Strong J, et al. Awareness typologies, long-term emotional adjustment and psychosocial outcomes following acquired brain injury. Neuropsychol Rehabil. 04. 2007;17(2):129-50. X-1. [pmid: 17454690].
1278 Ownsworth T, Little T, Turner B, et al. Assessing emotional status following acquired brain injury: the clinical potential of the depression, anxiety and stress scales. Brain Inj. 10. 2008;22(11):858-69. X-1, X-5. [pmid: 18850344].
1279 Ownsworth TL, Oei TPS. Depression after traumatic brain injury: Conceptualization and treatment considerations. Brain Injury. 09. 1998;12(9):735-751. X-2. [pmid: 9755365].
1280 Ozer FD, Yurt A, Sucu HK, et al. Depressed fractures over cranial venous sinus. J Emerg Med. 08. 2005;29(2):137-9. X-1, X-3, X-5. [pmid: 16029821].
1281 Ozturk S, Bozkurt A, Durmus M, et al. Psychiatric analysis of suicide attempt subjects due to maxillofacial gunshot. J Craniofac Surg. 11. 2006;17(6):1072-5. X-1, X-5. [pmid: 17119407].
1282 Paci GM, Sise MJ, Sise CB, et al. The need for immediate computed tomography scan after emergency craniotomy for head injury. J Trauma. 02. 2008;64(2):326-33. discussion 333–4. X-1. [pmid: 18301194].
1283 Packard RC, Ham LP. Evaluation of cognitive evoked potentials in post-traumatic headache cases with cognitive dysfunction. Headache Quarterly, Current Treatment & Research. 1996;7(3):218-24. X-1.
1284 Padala PR, List D, Petty F, et al. Adjunctive aripiprazole in combat-related posttraumatic stress disorder [letter]. Annals of Pharmacotherapy. 10. 2007;41(10):1744. X-5. [pmid: 17848426].
1285 Pae CU, Marks DM, Han C, et al. Does minocycline have antidepressant effect? Biomedicine &. Pharmacotherapy. 2008;62(5):308-311. X-2.
1286 Pagulayan KF, Hoffman JM, Temkin NR, et al. Functional limitations and depression after traumatic brain injury: examination of the temporal relationship. Arch Phys Med Rehabil. 10. 2008;89(10):1887-92. X-1. [pmid: 18929017].
1287 Pakalnis A, Paolicchi J. Frequency of secondary conversion symptoms in children with psychogenic nonepileptic seizures. Epilepsy Behav. 12. 2003;4(6):753-6. X-1, X-5. [pmid: 14698712].
1288 Palav A, Ortega A, McCaffrey RJ. Incremental validity of the MMPI-2 Content Scales: a preliminary study with brain-injured patients. J Head Trauma Rehabil. 06. 2001;16(3):275-83. X-5. [pmid: 11346449].
1289 Palmer AM, Marion DW, Botscheller ML, et al. Increased transmitter amino acid concentration in human ventricular CSF after brain trauma. Neuroreport. 12. 30. 1994;6(1):153-6. X-1, X-5. [pmid: 7703404].
1290 Paparrigopoulos T, Melissaki A, Efthymiou A, et al. Short-term psychological impact on family members of intensive care unit patients. J Psychosom Res. 11. 2006;61(5):719-22. X-1. [pmid: 17084152].
1291 Paradee CV, Rapport LJ, Lumley MA, et al. Circadian preference and facial emotion recognition among rehabilitation inpatients. Rehabilitation Psychology. 2008;53(1):46-53. X-1.
1292 Paradiso S, Chemerinski E, Yazici KM, et al. Frontal lobe syndrome reassessed: comparison of patients with lateral or medial frontal brain damage. J Neurol Neurosurg Psychiatry. 11. 1999;67(5):664-7. X-5. [pmid: 10519877].
1293 Parcell DL, Ponsford JL, Redman JR, et al. Poor sleep quality and changes in objectively recorded sleep after traumatic brain injury: a preliminary study. Arch Phys Med Rehabil. 05. 2008;89(5):843-50. X-5. [pmid: 18452730].
1294 Park YS, Eom S, Shim KW, et al. Neurocognitive and psychological profiles in pediatric arachnoid cyst. Childs Nerv Syst. 09. 2009;25(9):1071-6. X-1, X-3. [pmid: 19357855].
1295 Parkin M, Hopwood S, Jones DA, et al. Dynamic changes in brain glucose and lactate in pericontusional areas of the human cerebral cortex, monitored with rapid sampling online microdialysis: relationship with depolarisation-like events. J Cereb Blood Flow Metab. 03. 2005;25(3):402-13. X-1. [pmid: 15703701].
1296 Parsonage M. The differential diagnosis of seizures. J R Coll Physicians Lond. 04. 1973;7(3):213-34. X-1. [pmid: 4698374].
1297 Parsons LC, Shogan JS. The effects of the endotracheal tube suctioning/manual hyperventilation procedure on patients with severe closed head injuries. Heart Lung. 07. 1984;13(4):372-80. X-1. [pmid: 6564106].
1298 Parsons S. My artistic life: an unintentional therapy with unexpected results. Canadian Art Therapy Association Journal. Spring. 2005;18(1):28-32. X-1, X-2, X-5.
1299 Patrick DL, Topolski TD, Edwards TC, et al. Measuring the quality of life of youth with facial differences. Cleft Palate Craniofac J. 09. 2007;44(5):538-47. X-1, X-3. [pmid: 17760483].
1300 Patterson DE, Braverman SE, Belandres PV. Speech dysfunction due to trazodonefluoxetine combination in traumatic brain injury. Brain Injury. 1997;11(4):287-291. X-1, X-2, X-5. [pmid: 9134203].
1301 Payne HC. Traumatic brain injury, depression and cannabis use - Assessing their effects on a cognitive performance. Brain Injury. 2000;14(5):479-489. X-2, X-5. [pmid: 10834343].
1302 Pearson BW, Barber HO. Head injury. Some otoneurologic sequelae. Arch Otolaryngol. 01. 1973;97(1):81-4. X-1, X-5. [pmid: 4684911].
1303 Pelletier PM, Alfano DP. Depression, social support, and family coping following traumatic brain injury. Brain and Cognition. Special Issue: 9th Annual Rotman Research Inst Conference “Traumatic brain injury: Diagnosis, outcome, & rehabilitation”. March 24–26, 1999. 10. 2000;44(1):45-49. X-5.
1304 Pelsers MM, Hanhoff T, Van der Voort D, et al. Brain-and heart-type fatty acid-binding proteins in the brain: tissue distribution and clinical utility. Clin Chem. 09. 2004;50(9):1568-75. X-1. [pmid: 15217991].
1305 Pentelenyi T. Significance of endocrine studies in the general assessment and prediction of fatal outcome in head injury. Acta Neurochir Suppl (Wien). 1992;55:21-4. X-1. [pmid: 1414538].
1306 Pentland B, Hutton LS, Jones PA. Late mortality after head injury. J Neurol Neurosurg Psychiatry. 03. 2005;76(3):395-400. X-1. [pmid: 15716535].
1307 Perahia DGS, Maina G, Thase ME, et al. Duloxetine in the prevention of depressive recurrences: A randomized, double-blind, placebo-controlled trial. Journal of Clinical Psychiatry. 2009;70(5):706-716. X-1. [pmid: 19552867].
1308 Pereira EAC, Wang S, Paterson DJ, et al. Sustained reduction of hypertension by deep brain stimulation. Journal of Clinical Neuroscience. 2010;17(1):124-127. X-1, X-5. [pmid: 19664927].
1309 Perino C, Rago R, Cicolini A, et al. Mood and behavioural disorders following traumatic brain injury: clinical evaluation and pharmacological management. Brain Inj. 02. 2001;15(2):139-48. X-5. [pmid: 11260764].
1310 Perkins GD, Chatterjee S, Giles S, et al. Safety and tolerability of nonbronchoscopic lavage in ARDS. Chest. 04. 2005;127(4):1358-63. X-1. [pmid: 15821216].
1311 Perlman BB. Schizophrenia: a postulated animal model. Med Hypotheses. 11–12. 1976;2(6):238-40. X-1, X-3. [pmid: 1004302].
1312 Perna R. Major Depression and Suicidality Following Brain Injury. Journal of Cognitive Rehabilitation. Spr. 2005;23(1):5-7. X-2.
1313 Perna RB, Rouselle A, Brennan P. Traumatic brain injury: Depression, neurogenesis, and medication management. Journal of Head Trauma Rehabilitation. 03–04. 2003;18(2):201-203. X-2. [pmid: 12802228].
1314 Perron BE, Howard MO. Prevalence and correlates of traumatic brain injury among delinquent youths. Crim Behav Ment Health. 2008;18(4):243-55. X-3. [pmid: 18803295].
1315 Persinger MA. Sense of a presence and suicidal ideation following traumatic brain injury: indications of right-hemispheric intrusions from neuropsychological profiles. Psychol Rep. 12. 1994;75(3 Pt 1):1059-70. X-1. [pmid: 7892368].
1316 Persinger MA. Depression following brain trauma is enhanced in patients with mild discrepancies between intelligence and impairment on neuropsychological scores. Percept Mot Skills. 06. 1997;84(3 Pt 2):1284-6. X-1. [pmid: 9229447].
1317 Persinger MA. Subjective improvement following treatment with carbamazepine (Tegretol) for a subpopulation of patients with traumatic brain injuries. Percept Mot Skills. 02. 2000;90(1):37-40. X-5. [pmid: 10769880].
1318 Pessar LF, Coad ML, Linn RT, et al. The effects of parental traumatic brain injury on the behaviour of parents and children. Brain Inj. 05–06. 1993;7(3):231-40. X-1, X-5. [pmid: 8508179].
1319 Petchprapai N. Adaptation to mild traumatic brain injury among Thai adults. Case Western Reserve University. 2007:312. X-7.
1320 Petzold GC, Windmuller O, Haack S, et al. Increased extracellular K+ concentration reduces the efficacy of N-methyl-D-aspartate receptor antagonists to block spreading depression-like depolarizations and spreading ischemia. Stroke. 06. 2005;36(6):1270-7. X-1, X-3, X-5. [pmid: 15879337].
1321 Phalen JJ, Baumel JJ, Kaplan PA. Orbital floor fractures: a reassessment of pathogenesis. Nebr Med J. 05. 1990;75(5):100-3. X-1, X-3, X-5.
1322 Philip T, Chauvin F, Armitage J, et al. Parma international protocol: pilot study of DHAP followed by involved-field radiotherapy and BEAC with autologous bone marrow transplantation. Blood. 04. 1. 1991;77(7):1587-92. X-1. [pmid: 2009374].
1323 Philippi CL, Mehta S, Grabowski T, et al. Damage to association fiber tracts impairs recognition of the facial expression of emotion. J Neurosci. 12. 2. 2009;29(48):15089-99. X-1. [pmid: 19955360].
1324 Piccinelli M, Patterson M, Braithwaite I, et al. Anxiety and depression disorders 5 years after severe injuries: a prospective follow-up study. J Psychosom Res. 05. 1999;46(5):455-64. X-1, X-4. [pmid: 10404480].
1325 Piccolino P, Vetrano S, Mundula P, et al. Frontal bone fractures: new technique of closed reduction. J Craniofac Surg. 05. 2007;18(3):695-8. X-1, X-5. [pmid: 17538341].
1326 Piilgaard H, Lauritzen M. Persistent increase in oxygen consumption and impaired neurovascular coupling after spreading depression in rat neocortex. J Cereb Blood Flow Metab. 09. 2009;29(9):1517-27. X-1, X-3. [pmid: 19513087].
1327 Pincus JH. Ethical issues in forensic neurology. Semin Neurol. 03. 1984;4(1):87-91. X-1. [pmid: 11649671].
1328 Piskunowicz M, Krzyzanowski M, Lass P, et al. The usefulness of CBF brain SPECT in forensic medicine: The civil law code cases. A description of four cases. Nuclear Medicine Review. 2003;6(1):45-47. X-1, X-5. [pmid: 14600933].
1329 Platz T, Denzler P. Do psychological variables modify motor recovery among patients with mild arm paresis after stroke or traumatic brain injury who receive the Arm Ability Training. Restor Neurol Neurosci. 2002;20(1–2):37-49. X-1, X-5. [pmid: 12237495].
1330 Plese JP, Humphreys RP. The use of prophylactic systemic antibiotics in compound depressed skull fractures in infancy and childhood. Arq Neuropsiquiatr. 09. 1981;39(3):286-8. X-1, X-3, X-5. [pmid: 7325868].
1331 Plum F, Posner JB. The diagnosis of stupor and coma. Contemp Neurol Ser. 1972;10:1-286. X-1. [pmid: 4664014].
1332 Podnieks I, Doust JW. Spontaneous rhythms of perceptual motor performance in intact and damaged brain of man. Biol Psychol. 11. 1975;3(3):201-12. X-1. [pmid: 1203404].
1333 Pohlmann-Eden B, Bruckmeir J. Predictors and dynamics of posttraumatic epilepsy. Acta Neurol Scand. 05. 1997;95(5):257-62. X-1, X-4. [pmid: 9188898].
1334 Polman CH, O’Connor PW, Havrdova E, et al. A randomized, placebo-controlled trial of natalizumab for relapsing multiple sclerosis. New England Journal of Medicine. 2006;354(9):899-910. X-1. [pmid: 16510744].
1335 Pomeranz JL, Shaw LR, Yu NS, et al. Polytrauma and life care planning: Managing the complex interaction of multiple injuries. Work. 2008;31(3):319-326. X-1, X-2. [pmid: 19029673].
1336 Ponsford J, Draper K, Schonberger M. Functional outcome 10 years after traumatic brain injury: its relationship with demographic, injury severity, and cognitive and emotional status. J Int Neuropsychol Soc. 03. 2008;14(2):233-42. X-1. [pmid: 18282321].
1337 Ponsford J, Olver J, Ponsford M, et al. Long-term adjustment of families following traumatic brain injury where comprehensive rehabilitation has been provided. Brain Inj. 06. 2003;17(6):453-68. X-1. [pmid: 12745702].
1338 Ponsford J, Whelan-Goodinson R, Bahar-Fuchs A. Alcohol and drug use following traumatic brain injury: a prospective study. Brain Inj. 12. 2007;21(13–14):1385-92. X-1, X-5. [pmid: 18066940].
1339 Ponsford J, Willmott C, Rothwell A, et al. Cognitive and behavioral outcome following mild traumatic head injury in children. J Head Trauma Rehabil. 08. 1999;14(4):360-72. X-3. [pmid: 10407209].
1340 Ponsford J, Ziino C. Fatigue and Attention Following Traumatic Brain Injury. Zeitschrift fur Neuropsychologie. 08. 2003;14(3):155-163. X-5.
1341 Pope EJ, Smith OC. Identification of traumatic injury in burned cranial bone: an experimental approach. J Forensic Sci. 05. 2004;49(3):431-40. X-1. [pmid: 15171155].
1342 Posey S. Veterans and suicide: a review of potential increased risk. Smith College Studies in Social Work (Haworth). 2009;79(3–4):368-374. X-1, X-2.
1343 Potter JF, Fruin AH. Chronic subdural hematoma--the “great imitator”. Geriatrics. 06. 1977;32(6):61-6. X-1, X-2, X-4, X-5. [pmid: 863266].
1344 Potter-Efron RT. Differential diagnosis of physiological, psychiatric and sociocultural conditions associated with aggression and substance abuse. Journal of Chemical Dependency Treatment. Special Issue: Aggression, family violence and chemical dependency. 1989;3(1):37-59. X-2.
1345 Powell GE, Wilson SL. Recovery curves for patients who have suffered very severe brain injury. Clinical Rehabilitation. 1994;8(1):54-69. X-5.
1346 Powell J, Kitchen N, Heslin J, et al. Psychosocial outcomes at three and nine months after good neurological recovery from aneurysmal subarachnoid haemorrhage: predictors and prognosis. J Neurol Neurosurg Psychiatry. 06. 2002;72(6):772-81. X-1. [pmid: 12023423].
1347 Powell JH, al-Adawi S, Morgan J, et al. Motivational deficits after brain injury: effects of bromocriptine in 11 patients. J Neurol Neurosurg Psychiatry. 04. 1996;60(4):416-21. X-5. [pmid: 8774407].
1348 Powell T, Ekin-Wood A, Collin C. Post-traumatic growth after head injury: a longterm follow-up. Brain Inj. 01. 2007;21(1):31-8. X-1. [pmid: 17364517].
1349 Powell TJ, Collin C, Sutton K. A follow-up study of patients hospitalized after minor head injury. Disabil Rehabil. 05. 1996;18(5):231-7. X-5. [pmid: 8743300].
1350 Preece MH, Geffen GM. The contribution of pre-existing depression to the acute cognitive sequelae of mild traumatic brain injury. Brain Inj. 08. 2007;21(9):951-61. X-1, X-5. [pmid: 17729048].
1351 Presecki P, Mimica N. Involuntary emotional expression disorder - new/old disease in psychiatry and neurology. Psychiatr Danub. 09. 2007;19(3):184-8. X-1, X-2, X-4, X-5. [pmid: 17914317].
1352 Preti A, Cardascia L, Zen T, et al. Obstetric complications in patients with depression--a population-based case-control study. J Affect Disord. 12. 2000;61(1–2):101-6. X-1, X-5. [pmid: 11099747].
1353 Prigatano GP, Gray JA. Parental concerns and distress after paediatric traumatic brain injury: a qualitative study. Brain Inj. 06. 2007;21(7):721-9. X-1. [pmid: 17653946].
1354 Prigatano GP, Pribram KH. Perception and memory of facial affect following brain injury. Percept Mot Skills. 06. 1982;54(3):859-69. X-1. [pmid: 7099895].
1355 Probst C, Zelle BA, Sittaro NA, et al. Late death after multiple severe trauma: when does it occur and what are the causes. J Trauma. 04. 2009;66(4):1212-7. X-1. [pmid: 19359940].
1356 Procaccio F, Bingham RM, Hinds CJ, et al. Continuous EEG and ICP monitoring as a guide to the administration of althesin sedation in severe head injury. Intensive Care Med. 1988;14(2):148-55. X-1. [pmid: 3361020].
1357 Procaccio F, Menasce G, Sacchi L, et al. Effects of thiopentone and mannitol on cerebral perfusion pressure and E.E.G. in head injured patients with intracranial hypertension. Agressologie. 1991;32(8–9 Spec No):381-5. X-1. [pmid: 1844198].
1358 Pugliatti M, Sobocki P, Beghi E, et al. Cost of disorders of the brain in Italy. Neurol Sci. 04. 2008;29(2):99-107. X-1. [pmid: 18483707].
1359 Puskas CM. Bilateral fractures of the coronoid processes: differential diagnosis of intraoral gunshot trauma and scavenging using a sheep crania model. J Forensic Sci. 11. 2003;48(6):1219-25. X-1, X-3, X-5. [pmid: 14640263].
1360 Qasim MM. Total body irradiation as a primary therapy in non-Hodgkin lymphoma. Clin Radiol. 05. 1979;30(3):287-6. X-1. [pmid: 378510].
1361 Quattrocchi KB, Frank EH, Miller CH, et al. Impairment of helper T-cell function and lymphokine-activated killer cytotoxicity following severe head injury. J Neurosurg. 11. 1991;75(5):766-73. X-1, X-5. [pmid: 1833515].
1362 Quattrocchi KB, Miller CH, Wagner FC Jr, et al. Cell-mediated immunity in severely head-injured patients: the role of suppressor lymphocytes and serum factors. J Neurosurg. 11. 1992;77(5):694-9. X-1, X-5. [pmid: 1403109].
1363 Quinn DK, Flaherty AW, Herman JB, et al. Over the rainbow: A case of traumatic brain injury. Harvard Review of Psychiatry. 2010;18(1):56-66. X-5. [pmid: 20047461].
1364 Quintana DA, Parker JR, Jordan FB, et al. The spectrum of pediatric injuries after a bomb blast. J Pediatr Surg. 02. 1997;32(2):307-10. discussion 310–1. X-1, X-3. [pmid: 9044142].
1365 Rabinstein AA, Chung SY, Rudzinski LA, et al. Seizures after evacuation of subdural hematomas: incidence, risk factors, and functional impact. J Neurosurg. 02. 2010;112(2):455-60. X-1, X-5. [pmid: 19698050].
1366 Rahimi SY, Singh H, Yeh DJ, et al. Golf-associated head injury in the pediatric population: a common sports injury. J Neurosurg. 03. 2005;102(2 Suppl):163-6. X-1, X-3. [pmid: 16156225].
1367 Raimondi AJ, Hirschauer J. Head injury in the infant and toddler. Coma scoring and outcome scale. Childs Brain. 1984;11(1):12-35. X-1, X-3. [pmid: 6705608].
1368 Raine A, Lencz T, Bihrle S, et al. Reduced prefrontal gray matter volume and reduced autonomic activity in antisocial personality disorder. Arch Gen Psychiatry. 02. 2000;57(2):119-27. discussion 128–9. X-1. [pmid: 10665614].
1369 Raja IA, Vohra AH, Ahmed M. Neurotrauma in Pakistan. World J Surg. 09. 2001;25(9):1230-7. X-1. [pmid: 11571963].
1370 Rajkumar AP, Thangadurai P, Senthilkumar P, et al. Nature, prevalence and factors associated with depression among the elderly in a rural south Indian community. Int Psychogeriatr. 04. 2009;21(2):372-8. X-1. [pmid: 19243657].
1371 Rao N. Suicide after successful rehabilitation of traumatic brain injury. Archives of Physical Medicine and Rehabilitation. [Meeting]. 1991;72(10):818. X-7.
1372 Rao V, Bertrand M, Rosenberg P, et al. Predictors of new-onset depression after mild traumatic brain injury. The Journal of Neuropsychiatry and Clinical Neurosciences. Win. 2010;22(1):100-104. X-5. [pmid: 20160216].
1373 Rao V, Spiro J, Degoankar M, et al. Lesion location in depression post traumatic brain injury using magnetic resonance spectroscopy: Preliminary results from a pilot study. European Journal of Psychiatry. 2006;20(2):65-73. X-1, X-5.
1374 Rapoport AM, Sheftell FD, Baskin SM. Geriatric headaches. Geriatrics. 05. 1983;38(5):81-3. 86. 7. X-1. [pmid: 6840554].
1375 Rappaport M, Herrero-Backe C, Rappaport ML, et al. Head injury outcome up to ten years later. Arch Phys Med Rehabil. 12. 1989;70(13):885-92. X-1. [pmid: 2596962].
1376 Rapport LJ, Kreutzer JS, Hart T, et al. Traumatic brain injury caregiver distress and use of support services. Journal of Head Trauma Rehabilitation. 2006;21(5):432-3. X-1.
1377 Raskin SA. The relationship between sexual abuse and mild traumatic brain injury. Brain Inj. 08. 1997;11(8):587-603. X-5. [pmid: 9251867].
1378 Rathlev NK, Medzon R, Lowery D, et al. Intracranial pathology in elders with blunt head trauma. Acad Emerg Med. 03. 2006;13(3):302-7. X-1. [pmid: 16514123].
1379 Rathore MF, Rashid P, Butt AW, et al. Epidemiology of spinal cord injuries in the 2005 Pakistan earthquake. Spinal Cord. 10. 2007;45(10):658-63. X-1. [pmid: 17228354].
1380 Rayel MG. Clinical and demographic characteristics of elderly offenders at a maximumsecurity forensic hospital. J Forensic Sci. 11. 2000;45(6):1193-6. X-1. [pmid: 11110169].
1381 Raymond D, Crawford G, Van Ee C, et al. Development of biomechanical response corridors of the head to blunt ballistic temporo-parietal impact. J Biomech Eng. 09. 2009;131(9):094506. X-1, X-3, X-5. [pmid: 19725703].
1382 Raymond D, Van Ee C, Crawford G, et al. Tolerance of the skull to blunt ballistic temporo-parietal impact. J Biomech. 11. 13. 2009;42(15):2479-85. X-1, X-2, X-5. [pmid: 19674749].
1383 Raynor R, Parsa M. Nonsurgical elevation of depressed skull facture in an infant. J Pediatr. 02. 1968;72(2):262-4. X-1. [pmid: 5635809].
1384 Read KM, Burgess AR, Dischinger PC, et al. Psychosocial and physical factors associated with lower extremity injury. Annu Proc Assoc Adv Automot Med. 2002;46:289-303. X-1. [pmid: 12361514].
1385 Read KM, Kufera JA, Dischinger PC, et al. Life-altering outcomes after lower extremity injury sustained in motor vehicle crashes. Journal of Trauma: Injury, Infection, and Critical Care. 10. 2004;57(4):815-823. X-1, X-5.
1386 Reed GM, Spaulding WD, Bufka LF. The relevance of the International Classification of Functioning, Disability and Health (ICF) to mental disorders and their treatment. Alter. 2009;3(4):340-359. X-1, X-2.
1387 Rees RJ, Bellon ML. Post concussion syndrome ebb and flow: longitudinal effects and management. NeuroRehabilitation. 2007;22(3):229-42. X-5. [pmid: 17917173].
1388 Regan J, Regan WM, Hamer G, et al. Trauma-induced psychiatric disorders and civil law. Tenn Med. 11. 2004;97(11):508-9. X-1, X-2, X-4, X-5. [pmid: 15620207].
1389 Reger MA, Gahm GA, Swanson RD, et al. Association between number of deployments to Iraq and mental health screening outcomes in US army soldiers. Journal of Clinical Psychiatry. Published online 11 August 2009. 2009. X-1.
1390 Rehman L, Ghani E, Hussain A, et al. Infection in compound depressed fracture of the skull. J Coll Physicians Surg Pak. 03. 2007;17(3):140-3. X-1. [pmid: 17374298].
1391 Reichert WH, Blass JP. A placebo-controlled trial shows no effect of vasopressin on recovery from closed head injury. Ann Neurol. 10. 1982;12(4):390-2. X-1, X-5. [pmid: 6756285].
1392 Reilly HP Jr, Erbengi A, Sachs E Jr, et al. Penetration of the sagittal sinus by a depressed skull fracture. Roentgenographic diagnosis in an asymptomatic boy. JAMA. 11. 20. 1967;202(8):841-2. X-1. [pmid: 6072522].
1393 Reis JP, Baumann B. Acquired brain injury: reflections of two professionals with ABI. J Clin Ethics. Winter. 2004;15(4):308-13. X-1, X-2, X-5. [pmid: 15830559].
1394 Reiter S, Kutcher SP. The head injured adolescent: A case report and review of the issues. Canadian Journal of Psychiatry Revue Canadienne de Psychiatrie. 1990;35(8):669-673. X-2, X-3. [pmid: 2282616].
1395 Reme CE, Rol P, Grothmann K, et al. Bright light therapy in focus: lamp emission spectra and ocular safety. Technol Health Care. 12. 1996;4(4):403-13. X-1. [pmid: 9042691].
1396 Rengachary SS, Ashan S. Sir Robert Boyle and his unique case report on depressed cranial fracture. Neurosurgery. 09. 2007;61(3):633-9. discussion 640. X-1, X-2. [pmid: 17881978].
1397 Resnick PJ. Defrocking the fraud: the detection of malingering. Isr J Psychiatry Relat Sci. 1993;30(2):93-101. X-1, X-2. [pmid: 8270391].
1398 Retnam KR, Jawahar G, Natarajan M. Midline depressed fractures of the skull. J Indian Med Assoc. 09. 1986;84(9):271-2. X-1. [pmid: 3559246].
1399 Reyes G, Carrasco N, Mun~oz T, et al. Management of massive pulmonary embolism using recombinant activated Factor VII. European Journal of Cardio Thoracic Surgery. 2008;33(6):1144-1145. X-1, X-2, X-5. [pmid: 18406163].
1400 Reynolds M, McCann SR. A comparison between regimens containing chemotherapy alone (busulfan and cyclophosphamide) and chemotherapy (V. RAPID) plus total body irradiation on marrow engraftment following allogeneic bone marrow transplantation. Eur J Haematol. 10. 1989;43(4):314-20. X-1. [pmid: 2684682].
1401 Reza F, Ikoma K, Chuma T, et al. Correlations between neuropsychological test results and P300 latency during silent-count and button-press tasks in post-traumatic brain injury patients. J Clin Neurosci. 11. 2006;13(9):917-22. X-5. [pmid: 17049245].
1402 Reza MF, Ikoma K, Ito T, et al. N200 latency and P300 amplitude in depressed mood post-traumatic brain injury patients. Neuropsychol Rehabil. 12. 2007;17(6):723-34. X-5. [pmid: 18030646].
1403 Rich JD, Zbylski JR, LaRossa D, et al. A simple method for rapid assessment of malar depression. Ann Plast Surg. 08. 1979;3(2):151-2. X-1. [pmid: 543647].
1404 Richardson JL, Martin EM, Jimenez N, et al. Neuropsychological functioning in a cohort of HIV infected women: Importance of antiretroviral therapy. Journal of the International Neuropsychological Society. 2002;8(6):781-793. X-1. [pmid: 12240742].
1405 Richardson JL, Nowicki M, Danley K, et al. Neuropsychological functioning in a cohort of HIV- and hepatitis C virus-infected women. AIDS. 10. 14. 2005;19(15):1659-67. X-1. [pmid: 16184036].
1406 Richter D, Hahn MP, Ostermann PA, et al. Vertical deceleration injuries: a comparative study of the injury patterns of 101 patients after accidental and intentional high falls. Injury. 11. 1996;27(9):655-9. X-1. [pmid: 9039364].
1407 Riley CG. After effects of head injuries. N Z Med J. 10. 1966;65(410):644-7. X-1, X-2, X-4, X-5. [pmid: 5224360].
1408 Riley GA. Stress and depression in family carers following traumatic brain injury: the influence of beliefs about difficult behaviours. Clin Rehabil. 01. 2007;21(1):82-8. X-1. [pmid: 17213245].
1409 Ringdal M, Plos K, Lundberg D, et al. Outcome after injury: Memories, health-related quality of life, anxiety, and symptoms of depression after intensive care. Journal of Trauma: Injury, Infection and Critical Care. 2009;66(4):1226-1233. X-1.
1410 Rivara FP. Epidemiology of violent deaths in children and adolescents in the United States. Pediatrician. 1983;12(1):3-10. X-1, X-3. [pmid: 6571108].
1411 Rivera P, Elliott TR, Berry JW, et al. Predictors of caregiver depression among community-residing families living with traumatic brain injury. NeuroRehabilitation. 2007;22(1):3-8. X-1. [pmid: 17379944].
1412 Rivera PA, Elliott TR, Berry JW, et al. Problem-solving training for family caregivers of persons with traumatic brain injuries: a randomized controlled trial. Arch Phys Med Rehabil. 05. 2008;89(5):931-41. X-1, X-2, X-5. [pmid: 18452743].
1413 Roberson GS. Comparison of outcomes after mild, complicated-mild, and moderate pediatric traumatic brain injury. University of Houston. 2004:105. X-3.
1414 Roberts AR, Kim JH. Exploring the effects of head injuries among battered women: A qualitative study of chronic and severe woman battering. Journal of Social Service Research. 2005;32(1):33-47. X-1.
1415 Roberts CB, Rafal R, Coetzer BR. Feedback of brain-imaging findings: Effect on impaired awareness and mood in acquired brain injury. Brain Injury. 05. 2006;20(5):485-497. X-5. [pmid: 16716995].
1416 Roberts MA, Verduyn WH, Manshadi FF, et al. Episodic symptoms in dysfunctioning children and adolescents following mild and severe traumatic brain injury. Brain Inj. 10. 1996;10(10):739-47. X-1, X-4, X-5. [pmid: 8879664].
1417 Robertson CS, Clifton GL, Grossman RG, et al. Alterations in cerebral availability of metabolic substrates after severe head injury. J Trauma. 11. 1988;28(11):1523-32. X-1, X-5. [pmid: 3184214].
1418 Robertson RH, Knight RG. Evaluation of social problem solving after traumatic brain injury. Neuropsychol Rehabil. 04. 2008;18(2):236-50. X-5. [pmid: 18350415].
1419 Robin M, Guardiola P, Devergie A, et al. A 10-year median follow-up study after allogeneic stem cell transplantation for chronic myeloid leukemia in chronic phase from HLA-identical sibling donors. Leukemia. 09. 2005;19(9):1613-20. X-1. [pmid: 15990868].
1420 Robins HI, Longo WL, Steeves RA, et al. Adjunctive therapy (whole body hyperthermia versus lonidamine) to total body irradiation for the treatment of favorable B-cell neoplasms: a report of two pilot clinical trials and laboratory investigations. Int J Radiat Oncol Biol Phys. 04. 1990;18(4):909-20. X-1. [pmid: 2182581].
1421 Robinson E, Rumsey N, Partridge J. An evaluation of the impact of social interaction skills training for facially disfigured people. Br J Plast Surg. 07. 1996;49(5):281-9. X-1, X-5. [pmid: 8774241].
1422 Robinson RG. Depression and antidepressants in patients with brain injury. Clin Neuropharmacol. 1992;15(Suppl 1 Pt A):638A-639A. X-1, X-5.
1423 Robinson RG, Benson DF. Depression in aphasic patients: frequency, severity, and clinical-pathological correlations. Brain Lang. 11. 1981;14(2):282-91. X-5. [pmid: 7306784].
1424 Robinson RG, Boston JD, Starkstein SE, et al. Comparison of mania and depression after brain injury: causal factors. Am J Psychiatry. 02. 1988;145(2):172-8. X-1, X-5. [pmid: 3341462].
1425 Robinson RG, Lipsey JR. Cerebral localization of emotion based on clinicalneuropathological correlations: methodological issues. Psychiatr Dev. Winter. 1985;3(4):335-47. X-1, X-2, X-4, X-5. [pmid: 3879361].
1426 Robinson RG, Szetela B. Mood change following left hemispheric brain injury. Ann Neurol. 05. 1981;9(5):447-53. X-5. [pmid: 7271239].
1427 Robinson-Smith G, Grill JD. Recognizing involuntary emotional expression disorder. J Neurosci Nurs. 08. 2007;39(4):202-7. X-1, X-2, X-4, X-5. [pmid: 17847666].
1428 Roccia F, Dell’Acqua A, Angelini G, et al. Maxillofacial trauma and psychiatric sequelae: post-traumatic stress disorder. J Craniofac Surg. 05. 2005;16(3):355-60. X-1. [pmid: 15915097].
1429 Rodgers ML, Strode AD, Norell DM, et al. Adapting multiple-family group treatment for brain and spinal cord injury intervention development and preliminary outcomes. Am J Phys Med Rehabil. 06. 2007;86(6):482-92. X-1, X-5. [pmid: 17515688].
1430 Rodin EA. Contribution of the EEG to prognosis after head injury. Dis Nerv Syst. 09. 1967;28(9):595-601. X-1, X-2, X-4, X-5. [pmid: 6052926].
1431 Rohling ML, Green P, Allen LM III, et al. Depressive symptoms and neurocognitive test scores in patients passing symptom validity tests. Archives of Clinical Neuropsychology. 04. 2002;17(3):205-222. X-1. [pmid: 14589724].
1432 Rolls ET, Hornak J, Wade D, et al. Emotion-related learning in patients with social and emotional changes associated with frontal lobe damage. J Neurol Neurosurg Psychiatry. 12. 1994;57(12):1518-24. X-1, X-5. [pmid: 7798983].
1433 Roma-Clifton M. A study of perceptual disturbance(s) in spinal cord injury patients in an acute rehabilitation hospital. Pacific Graduate School of Psychology. 1996:121. X-1.
1434 Roman I, Romila A, Voinea V. Contribution to the study of the value of EEG in psychiatrico-legal examination. Rev Roum Neurol Psychiatr. 1975;13(1):1-19. X-1, X-5. [pmid: 1135599].
1435 Ronnback L, Hansson E. On the potential role of glutamate transport in metal fatigue. Journal of Neuroinflammation. 2004;1(04). X-1.
1436 Ropacki MT, Elias JW. Preliminary examination of cognitive reserve theory in closed head injury. Arch Clin Neuropsychol. 08. 2003;18(6):643-54. X-1, X-5. [pmid: 14591438].
1437 Ropper AH. Lateral displacement of the brain and level of consciousness in patients with an acute hemispheral mass. N Engl J Med. 04. 10. 1986;314(15):953-8. X-1, X-5. [pmid: 3960059].
1438 Rosati DL. Early polyneuropharmacologic intervention in brain injury agitation. American Journal of Physical Medicine & Rehabilitation. 2002;81(2):90-93. X-5. [pmid: 11807342].
1439 Rosen CJ. Serotonin rising - the bone, brain, bowel connection. New England Journal of Medicine. 2009;360(10):957-959. X-1. [pmid: 19264685].
1440 Rosen DH, Hoffman AM. Focal suicide: self-enucleation by two young psychotic individuals. Am J Psychiatry. 02. 1972;128(8):1009-12. X-1. [pmid: 4109987].
1441 Rosen HJ, Wilson MR, Schauer GF, et al. Neuroanatomical correlates of impaired recognition of emotion in dementia. Neuropsychologia. 2006;44(3):365-373. X-1. [pmid: 16154603].
1442 Rosenbaum M, Najenson T. Changes in life patterns and symptoms of low mood as reported by wives of severly brain-injured soldiers. J Consult Clin Psychol. 12. 1976;44(6):881-8. X-1, X-5. [pmid: 993425].
1443 Rosenblum J, Yousefzadeh DK, Ramilo JL. Skull radiography in infants: potential hazards of the use of head clamps. Radiology. 11. 1986;161(2):367-8. X-1, X-3, X-5. [pmid: 3763902].
1444 Rosenfeld JV. Neurosurgery in Rwanda during a United Nations peace-keeping mission. Mil Med. 05. 1997;162(5):311-4. X-1. [pmid: 9155097].
1445 Rosenthal JW. MMPI-2 correlates among out-patient rehabilitation TBI patients. Argosy University. Seattle. 2002:119. X-7.
1446 Ross SM. Profound retrograde amnesia following mild head injury: Organic or functional. Cortex. 2000;36(4):521-537. X-1, X-2, X-5. [pmid: 11059453].
1447 Ross SR, Putnam SH, Adams KM. Psychological disturbance, incomplete effort, and compensation-seeking status as predictors of neuropsychological test performance in head injury. J Clin Exp Neuropsychol. 01. 2006;28(1):111-25. X-1. [pmid: 16448980].
1448 Ross SR, Putnam SH, Gass CS, et al. MMPI-2 indices of psychological disturbance and attention and memory test performance in head injury. Arch Clin Neuropsychol. 12. 2003;18(8):905-6. X-1. [pmid: 14609584].
1449 Roth M. Seeking common ground in contemporary psychiatry. Proc R Soc Med. 08. 1969;62(8):765-72. X-1. [pmid: 5810284].
1450 Roubertoux PL, KerdelhuÃ© B. Special Issue Dedication: Trisomy 21: Brain and Cognitive Functioning. Behavior Genetics. 05. 2006;36(3):343-345. X-1, X-2, X-5.
1451 Roubicek J, Matousek M, Volavka J. The perspectives of research in psychiatric electroencephalography. II Clinical Electroencephalogr. Clin Neurophysiol. 02. 1969;26(2):233. X-1.
1452 Rouge-Maillart C, Jousset N, Gaudin A, et al. Women who kill their children. Am J Forensic Med Pathol. 12. 2005;26(4):320-6. X-1. [pmid: 16304463].
1453 Rounsaville B, Weissman MM. Battered women: a medical problem requiring detection. Int J Psychiatry Med. 1977;8(2):191-202. X-5. [pmid: 204589].
1454 Roy A. Hysteria: a case note study. Can J Psychiatry. 03. 1979;24(2):157-60. X-1, X-2, X-5. [pmid: 427703].
1455 RubÃ MCM. Neurofeedback around the world. Journal of Neurotherapy. 2006;10(4):63-73. X-1, X-2.
1456 Ruchholtz S, Pajonk FG, Waydhas C, et al. Long-term results and quality of life after parasuicidal multiple blunt trauma. Crit Care Med. 03. 1999;27(3):522-30. X-5. [pmid: 10199531].
1457 Ruddle JA, Coetzer BR, Vaughan FL. Grief after brain injury: a validation of the Brain Injury Grief Inventory (BIGI). Illness, Crisis & Loss. 2005;13(3):235-47. X-1, X-5.
1458 Rudman D, John A, Mattson DE, et al. Seizure disorder in the men of a Veterans Administration nursing home. J Clin Epidemiol. 1988;41(4):393-9. X-1. [pmid: 3280735].
1459 Rueda-Sanchez M, Diaz-Martinez LA. Prevalence and associated factors for episodic and chronic daily headache in the Colombian population. Cephalalgia. 2008;28(3):216-225. X-1. [pmid: 18254892].
1460 Ruedrich SL, Chu C-c, Moore SL. ECT for major depression in a patient with acute brain trauma. American Journal of Psychiatry. 07. 1983;140(7):928-929. X-5. [pmid: 6859320].
1461 Ruff RM, Niemann H. Cognitive rehabilitation versus day treatment in head-injured adults: is there an impact on emotional and psychosocial adjustment. Brain Inj. 10–12. 1990;4(4):339-47. X-5. [pmid: 2252966].
1462 Rusch MD, Grunert BK, Sanger JR, et al. Psychological adjustment in children after traumatic disfiguring injuries: a 12-month follow-up. Plast Reconstr Surg. 12. 2000;106(7):1451-8. discussion 1459–60. X-1, X-3. [pmid: 11129171].
1463 Russell DM. Rehabilitating individuals with serious brain injuries: Personality characteristics and the experience of loss. Walden University. 1999:165. X-7.
1464 Russman SB. Social skills training for children and adolescents with a traumatic brain injury. University Of Utah. 1997:167. X-1, X-3, X-5.
1465 Ruttan LA. Depression and neuropsychological functioning in mild traumatic brain injury. Dissertation Abstracts International: Section B: The Sciences and Engineering. 1998;59(5-B). X-7.
1466 Ruttan LA, Heinrichs RW. Depression and neurocognitive functioning in mild traumatic brain injury patients referred for assessment. J Clin Exp Neuropsychol. 05. 2003;25(3):407-19. X-1. [pmid: 12916653].
1467 Rutter M, Chadwick O, Shaffer D, et al. A prospective study of children with head injuries: I. Design and methods. Psychol Med. 11. 1980;10(4):633-45. X-3. [pmid: 7208723].
1468 Rutterford NA, Wood RL. Evaluating a theory of stress and adjustment when predicting long-term psychosocial outcome after brain injury. J Int Neuropsychol Soc. 05. 2006;12(3):359-67. X-1. [pmid: 16903128].
1469 Ryan AB. The role of chiropractic in trauma brain injury: a case study. Journal of Vertebral Subluxation Research. 2007;18:1-6. X-5.
1470 Ryan TV, Sautter SW, Capps CF, et al. Utilizing neuropsychological measures to predict vocational outcome in a head trauma population. Brain Inj. 03–04. 1992;6(2):175-82. X-1. [pmid: 1571722].
1471 Sabhesan S, Natarajan M. Long-term outcome following head injury. J Indian Med Assoc. 02. 1993;91(2):37-9. X-1. [pmid: 8501311].
1472 Sachdev P, Smith JS, Cathcart S. Schizophrenia-like psychosis following traumatic brain injury: a chart-based descriptive and case-control study. Psychol Med. 02. 2001;31(2):231-9. X-1, X-5. [pmid: 11232911].
1473 Sacks GS, Brown RO, Teague D, et al. Early nutrition support modifies immune function in patients sustaining severe head injury. JPEN J Parenter Enteral Nutr. 09–10. 1995;19(5):387-92. X-1, X-5. [pmid: 8577017].
1474 Saggese JA, Bruera OC. CT or MRI in posttraumatic headache. Headache: The Journal of Head and Face Pain. 07–08. 1998;38(7):554-555. X-5.
1475 Sakaino H. The biochemical study of intermaxillary fixation (IMF) stress in oral surgery inpatients. Kurume Med J. 2001;48(1):71-7. X-1. [pmid: 11402624].
1476 Sakas DE, Whittaker KW, Whitwell HL, et al. Syndromes of posttraumatic neurological deterioration in children with no focal lesions revealed by cerebral imaging: evidence for a trigeminovascular pathophysiology. Neurosurgery. 09. 1997;41(3):661-7. X-1, X-3. [pmid: 9310985].
1477 Salerian AJ, Saleri NG, Salerian JA. Brain temperature may influence mood: a hypothesis. Med Hypotheses. 2008;70(3):497-500. X-1, X-2. [pmid: 17951014].
1478 Sallee FR, Lyne A, Wigal T, et al. Long-Term safety and efficacy of guanfacine extended release in children and adolescents with attention-deficit/hyperactivity disorder. Journal of Child and Adolescent Psychopharmacology. 2009;19(3):215-226. X-1, X-3. [pmid: 19519256].
1479 Salloum IM, Jenkins EJ, Thompson B, et al. Treatment compliance and hostility levels of head-injured psychiatric outpatients. J Natl Med Assoc. 08. 1990;82(8):557-64. X-1, X-4, X-5. [pmid: 2395175].
1480 Salmond CH, Chatfield DA, Menon DK, et al. Cognitive sequelae of head injury: involvement of basal forebrain and associated structures. Brain. 01. 2005;128(Pt 1):189-200. X-5. [pmid: 15548553].
1481 Salmond CH, Menon DK, Chatfield DA, et al. Cognitive reserve as a resilience factor against depression after moderate/severe head injury. J Neurotrauma. 07. 2006;23(7):1049-58. X-5. [pmid: 16866618].
1482 Samuel C, Louis-Dreyfus A, Couillet J, et al. Dysprosody after severe closed head injury: an acoustic analysis. J Neurol Neurosurg Psychiatry. 04. 1998;64(4):482-5. X-1, X-5. [pmid: 9576539].
1483 Samuel E, Williams RB, Ferrell RB. Excited delirium: Consideration of selected medical and psychiatric issues. Neuropsychiatric Disease and Treatment. 2009;5(1):61-66. X-1, X-2. [pmid: 19557101].
1484 Sandel ME, Zwil AS. Psychopharmacologic treatment for affective disorders after traumatic brain injury. Physical Medicine & Rehabilitation Clinics of North America. 11. 1997;8(4):743-62. X-2.
1485 Sander AM, High WM Jr, Hannay HJ, et al. Predictors of psychological health in caregivers of patients with closed head injury. Brain Inj. 04. 1997;11(4):235-49. X-1, X-2, X-5. [pmid: 9134198].
1486 Sander AM, Kreutzer JS, Fernandez CC. Neurobehavioral functioning, substance abuse, and employment after brain injury: implications for vocational rehabilitation. Journal of Head Trauma Rehabilitation. 1997;12(5):28-41. X-1.
1487 Santos AB, Ballenger JC. Tricyclic antidepressant triggers mania in patient with organic affective disorder. Journal of Clinical Psychiatry. 10. 1992;53(10):377-378. X-5. [pmid: 1429478].
1488 Saran A. Antidepressants not effective in headache associated with minor closed head injury. Int J Psychiatry Med. 1988;18(1):75-83. X-5. [pmid: 3294202].
1489 Saran AS. Depression after minor closed head injury: role of dexamethasone suppression test and antidepressants. J Clin Psychiatry. 08. 1985;46(8):335-8. X-5. [pmid: 4019422].
1490 Sarll P. Head injury. Coming back to life. Nurs Times. 10. 13–19. 1993;89(41):28-31. X-1, X-2, X-5. [pmid: 8233902].
1491 Sato T, Takeichi M. A case of chronic subdural hematoma with anxiety states and concomitant regression-like symptoms. Japanese Journal of Psychiatry & Neurology. 1987;41(4):663-667. X-1. [pmid: 3134566].
1492 Satz P, Fennell E, Reilly C. Predictive validity of six neurodiagnostic tests: a decision theory analysis. J Consult Clin Psychol. 06. 1970;34(3):375-81. X-1. [pmid: 5523445].
1493 Sayer NA, Chiros CE, Sigford B, et al. Characteristics and rehabilitation outcomes among patients with blast and other injuries sustained during the Global War on Terror. Arch Phys Med Rehabil. 01. 2008;89(1):163-70. X-1. [pmid: 18164349].
1494 Scahill L, Erenberg G, Berlin CM Jr, et al. Contemporary Assessment and Pharmacotherapy of Tourette Syndrome NeuroRx. 2006;3(2):192-206. X-1, X-2, X-3, X-5.
1495 Scalco MZ, van Reekum R. Prevention of Alzheimer disease. Encouraging evidence. Can Fam Physician. 02. 2006;52:200-7. X-1, X-2. [pmid: 16529393].
1496 Schatz P, Hughes LJ, Chute DL. Underutilization of neuropsychology in traumatic brain injury rehabilitation: is managed care to blame. NeuroRehabilitation. 2001;16(4):281-7. X-1. [pmid: 11790915].
1497 Scheibel RS, Newsome MR, Troyanskaya M, et al. Effects of severity of traumatic brain injury and brain reserve on cognitive-control related brain activation. J Neurotrauma. 09. 2009;26(9):1447-61. X-1, X-5. [pmid: 19645622].
1498 Schimmel P. Mind over matter? II: Implications for psychiatry. Australian & New Zealand Journal of Psychiatry. 2001;35(4):488-494. X-1, X-2. [pmid: 11531730].
1499 Schlund MW, Pace G. Relations between traumatic brain injury and the environment: Feedback reduces maladaptive behaviour exhibited by three persons with traumatic brain injury. Brain Injury. 1999;13(11):889-897. X-5. [pmid: 10579660].
1500 Schmand B, Lindeboom J, Schagen S, et al. Cognitive complaints in patients after whiplash injury: the impact of malingering. J Neurol Neurosurg Psychiatry. 03. 1998;64(3):339-43. X-1. [pmid: 9527145].
1501 Schmeling A, Strauch H, Rothschild MA. Female suicides in Berlin with the use of firearms. Forensic Sci Int. 12. 27. 2001;124(2–3):178-81. X-1, X-5. [pmid: 11792508].
1502 Schmitt JA, Kruizinga MJ, Riedel WJ. Non-serotonergic pharmacological profiles and associated cognitive effects of serotonin reuptake inhibitors. J Psychopharmacol. 09. 2001;15(3):173-9. X-1, X-5. [pmid: 11565624].
1503 Schmitz N, Kugler J, Rollnik J. On the relation between neuroticism, self-esteem, and depression: results from the National Comorbidity Survey. Compr Psychiatry. 05–06. 2003;44(3):169-76. X-1. [pmid: 12764703].
1504 Schnaper N, Cowley RA. Overview: psychiatric sequelae to multiple trauma. Am J Psychiatry. 08. 1976;133(8):883-90. X-1, X-2, X-4, X-5. [pmid: 941998].
1505 Schnyder U, Malt UF. Acute stress response patterns to accidental injuries. J Psychosom Res. 11. 1998;45(5):419-24. X-1, X-5. [pmid: 9835235].
1506 Schnyder U, Moergeli H, Trentz O, et al. Prediction of psychiatric morbidity in severely injured accident victims at one-year follow-up. Am J Respir Crit Care Med. 08. 15. 2001;164(4):653-6. X-1. [pmid: 11520732].
1507 Schnyder U, Wittmann L, Friedrich-Perez J, et al. Posttraumatic stress disorder following accidental injury: rule or exception in Switzerland. Psychother Psychosom. 2008;77(2):111-8. X-1, X-5. [pmid: 18230944].
1508 Schoenberg MR, Duff K, Scott JG, et al. An evaluation of the clinical utility of the OPIE-3 as an estimate of premorbid WAIS-III FSIQ. Clin Neuropsychol. 08. 2003;17(3):308-21. X-1, X-5. [pmid: 14704882].
1509 Schoenberg MR, Lange RT, Iverson GL, et al. Clinical validation of the General Ability Index--Estimate (GAI-E): estimating premorbid GAI. Clin Neuropsychol. 09. 2006;20(3):365-81. X-5. [pmid: 16895853].
1510 Schoenberger NE, Shif SC, Esty ML, et al. Flexyx Neurotherapy System in the treatment of traumatic brain injury: an initial evaluation. J Head Trauma Rehabil. 06. 2001;16(3):260-74. X-5. [pmid: 11346448].
1511 Schoenhuber R, Gentilini M. Anxiety and depression after mild head injury: a case control study. J Neurol Neurosurg Psychiatry. 05. 1988;51(5):722-4. X-5. [pmid: 3404171].
1512 Schoenhuber R, Gentilini M, Orlando A. Prognostic value of auditory brain-stem responses for late postconcussion symptoms following minor head injury. J Neurosurg. 05. 1988;68(5):742-4. X-4. [pmid: 3357034].
1513 Schonberger M, Humle F, Teasdale TW. Subjective outcome of brain injury rehabilitation in relation to the therapeutic working alliance, client compliance and awareness. Brain Inj. 11. 2006;20(12):1271-82. X-1, X-5. [pmid: 17132550].
1514 Schooler C, Caplan LJ, Revell AJ, et al. Brain lesion and memory functioning: short-term memory deficit is independent of lesion location. Psychon Bull Rev. 06. 2008;15(3):521-7. X-1, X-5. [pmid: 18567249].
1515 Schopp LH, Johnstone BR, Merveille OC. Multidimensional telecare strategies for rural residents with brain injury. J Telemed Telecare. 2000;6(Suppl 1):S146-9. X-1, X-4, X-5. [pmid: 10794002].
1516 Schrager GO. Elevation of depressed skull fracture with a breast pump. J Pediatr. 08. 1970;77(2):300-1. X-1. [pmid: 5464406].
1517 Schuld A, Archelos JJ, Friess E. Visual hallucinations and psychotic symptoms during treatment with selective serotonin reuptake inhibitors: Is the sigma receptor involved?. Journal of Clinical Psychopharmacology. 10. 2000;20(5):579. X-5. [pmid: 11001244].
1518 Schulz-Kindermann F, Hennings U, Ramm G, et al. The role of biomedical and psychosocial factors for the prediction of pain and distress in patients undergoing highdose therapy and BMT/PBSCT. Bone Marrow Transplant. 02. 2002;29(4):341-51. X-1. [pmid: 11896432].
1519 Schunk JE, Rodgerson JD, Woodward GA. The utility of head computed tomographic scanning in pediatric patients with normal neurologic examination in the emergency department. Pediatr Emerg Care. 06. 1996;12(3):160-5. X-1, X-3. [pmid: 8806136].
1520 Schutzman SA, Barnes PD, Mantello M, et al. Epidural hematomas in children. Ann Emerg Med. 03. 1993;22(3):535-41. X-3. [pmid: 8442541].
1521 Schwalb JM, Hamani C. The History and Future of Deep Brain Stimulation. Neurotherapeutics. 2008;5(1):3-13. X-1, X-2, X-3, X-5. [pmid: 18164479].
1522 Scott DA, Beilby DS, McClymont C. Postoperative analgesia using epidural infusions of fentanyl with bupivacaine. A prospective analysis of 1,014 patients. Anesthesiology. 10. 1995;83(4):727-37. X-1. [pmid: 7574052].
1523 Scragg P, Jones A, Fauvel N. Psychological problems following ICU treatment. Anaesthesia. 01. 2001;56(1):9-14. X-1, X-5. [pmid: 11167429].
1524 Seddik Z, Habib YA, el Shamy E. The prognostic value of the brain sodiumpotassium ATPase enzyme concentration in head injury. Childs Nerv Syst. 06. 1991;7(3):135-8. X-1, X-5. [pmid: 1652353].
1525 Segalowitz SJ, Lawson S. Subtle symptoms associated with self-reported mild head injury. J Learn Disabil. 05. 1995;28(5):309-19. X-1. [pmid: 7775851].
1526 Seib TP, Price R, Reyes MR, et al. The quantitative measurement of spasticity: effect of cutaneous electrical stimulation. Arch Phys Med Rehabil. 07. 1994;75(7):746-50. X-1, X-3. [pmid: 8024418].
1527 Seiff SR, Good WV. Hypertropia and the posterior blowout fracture: Mechanism and management. Ophthalmology. 01. 1996;103(1):152-6. X-1, X-5. [pmid: 8628546].
1528 Selig C, Kreja L, Muller H, et al. Hematologic effects of recombinant human interleukin-6 in dogs exposed to a total-body radiation dose of 2.4 Gy. Exp Hematol. 07. 1994;22(7):551-8. X-1, X-3. [pmid: 8013570].
1529 Seligman R. A psychiatric classification system for burned children. Am J Psychiatry. 01. 1974;131(1):41-6. X-1. [pmid: 4127932].
1530 Semlyen JK, Summers SJ, Barnes MP. Aspects of caregiver distress after severe head injury. Journal of Neurologic Rehabilitation. 1998;12(2):53-9. X-5.
1531 Sen P, Ross N, Rogers S. Recovering maxillofacial trauma patients: the hidden problems. J Wound Care. 03. 2001;10(3):53-7. X-1, X-5. [pmid: 11924351].
1532 Shaffer D, Chadwick O, Rutter M. Psychiatric outcome of localized head injury in children. Ciba Found Symp. 1975;(34):191-213. X-3. [pmid: 816623].
1533 Shaffer MA, Doris PE. Increasing the diagnostic yield of portable skull films. Ann Emerg Med. 06. 1982;11(6):303-6. X-1. [pmid: 7081791].
1534 Shank B, Brochstein JA, Castro-Malaspina H, et al. Immunosuppression prior to marrow transplantation for sensitized aplastic anemia patients: comparison of TLI with TBI. Int J Radiat Oncol Biol Phys. 06. 1988;14(6):1133-41. X-1, X-5. [pmid: 3290168].
1535 Shanon A, Feldman W. Management of moderate head injury in childhood: degree of consensus among Canadian pediatric emergency physicians. Pediatr Emerg Care. 12. 1994;10(6):322-5. X-1, X-5. [pmid: 7899114].
1536 Shapira M, Licht A, Milman A, et al. Role of glycogen synthase kinase-3beta in early depressive behavior induced by mild traumatic brain injury. Molecular & Cellular Neurosciences. 2007;34(4):571-577. X-1, X-4, X-5. [pmid: 17289399].
1537 Shearer VE, Gardner J, Murphy MT. Perioperative anesthetic management of maxillofacial trauma including ophthalmic injuries. Anesthesiology Clinics of North America. 1999;17(1):141-53. X-1, X-2, X-5.
1538 Shearn CR, Berry DF, Fitzgibbons DJ. Usefulness of the Memory-for-Designs Test in assessing mild organic complications in psychiatric patients. Percept Mot Skills. 06. 1974;38(3):1099-1104. X-1. [pmid: 4425114].
1539 Sheehan W, Thurber S. Psychosis or temporal lobotomy: SPECT findings in a paraplegic patient with chronic mental illness. Acta Psychiatrica Scandinavica. 2006;114(2):140-142. X-5. [pmid: 16836602].
1540 Sheehan W, Thurber S. Review of two years of experiences with SPECT among psychiatric patients in a rural hospital setting. J Psychiatr Pract. 09. 2008;14(5):318-23. X-1, X-4, X-5. [pmid: 18832964].
1541 Sheftell FD, Atlas SJ. Migraine and psychiatric comorbidity: from theory and hypotheses to clinical application. Headache. 10. 2002;42(9):934-44. X-1. [pmid: 12390624].
1542 Shepherd JG Jr. Coping style as mediator of health-related quality of life and depression after an acquired brain injury. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2007;68(2-B). X-7.
1543 Sher L. A model of suicidal behavior in war veterans with posttraumatic mood disorder. Med Hypotheses. 08. 2009;73(2):215-9. X-1. [pmid: 19327892].
1544 Shi XY, Tang ZQ, Sun D, et al. Evaluation of hyperbaric oxygen treatment of neuropsychiatric disorders following traumatic brain injury. Chin Med J (Engl). 12. 5. 2006;119(23):1978-82. X-1. [pmid: 17199942].
1545 Shiel A, Wilson BA. Can behaviours observed in the early stages of recovery after traumatic brain injury predict poor outcome. Neuropsychol Rehabil. 07–09. 2005;15(3–4):494-502. X-1, X-5. [pmid: 16350990].
1546 Shields LB, Hunsaker JC 3rd, Stewart DM. Russian roulette and risk-taking behavior: a medical examiner study. Am J Forensic Med Pathol. 03. 2008;29(1):32-9. X-1. [pmid: 19749614].
1547 Shirley PJ. Critical care delivery: the experience of a civilian terrorist attack. J R Army Med Corps. 03. 2006;152(1):17-21. X-1, X-5. [pmid: 16749465].
1548 Shokunbi MT, Komolafe EO, Malomo AO, et al. Scalp closure without fracture elevation does not reduce the risk of infection in patients with compound depressed skull fractures. Afr J Med Med Sci. 09–12. 2000;29(3–4):293-6. X-1. [pmid: 11714009].
1549 Shokunbi T, Olurin O. Childhood head injury in Ibadan: causes, neurologic complications and outcome. West Afr J Med. 04–03. 1994;13(1):38-42. X-1, X-3. [pmid: 8080830].
1550 Shukla S, Cook BL, Mukherjee S, et al. Mania following head trauma. Am J Psychiatry. 01. 1987;144(1):93-6. X-5. [pmid: 3799847].
1551 Shumrick KA, Kersten RC, Kulwin DR, et al. Criteria for selective management of the orbital rim and floor in zygomatic complex and midface fractures. Arch Otolaryngol Head Neck Surg. 04. 1997;123(4):378-84. X-1. [pmid: 9109783].
1552 Sidaros A, Engberg AW, Sidaros K, et al. Diffusion tensor imaging during recovery from severe traumatic brain injury and relation to clinical outcome: a longitudinal study. Brain. 02. 2008;131(Pt 2):559-72. X-5. [pmid: 18083753].
1553 Siegal JT, Robiner W, Smith S, et al. Cochlear implantation in severe traumatic brain injury and paranoid schizophrenia: Two case studies. Ear, Nose, & Throat Journal. 2005;84(8):498-508. X-1, X-5.
1554 Signer S, Cummings JL, Benson DF. Delusions and mood disorders in patients with chronic aphasia. J Neuropsychiatry Clin Neurosci. Winter. 1989;1(1):40-5. X-1, X-5. [pmid: 2535428].
1555 Silva AM, Ferreira MT. Signs of trauma in an adult parietal bone exhumed from a Portuguese prehistoric collective burial. Coll Antropol. 06. 2008;32(2):633-5. X-1, X-5. [pmid: 18756922].
1556 Silva MC, Gaunekar G, Patel V, et al. The prevalence and correlates of hazardous drinking in industrial workers: A study from Goa, India. Alcohol and Alcoholism. 2003;38(1):79-83. X-1. [pmid: 12554613].
1557 Silver FW. Management of conversion disorder. American Journal of Physical Medicine & Rehabilitation. 1996;75(2):134-140. X-1, X-5. [pmid: 8630194].
1558 Silver JM, Hales RE, Yudofsky SC. Psychopharmacology of depression in neurologic disorders. Journal of Clinical Psychiatry. 01. 1990;51(Suppl):33-39. X-2.
1559 Silver JM, Kramer R, Greenwald S, et al. The association between head injuries and psychiatric disorders: findings from the New Haven NIMH Epidemiologic Catchment Area Study. Brain Inj. 11. 2001;15(11):935-45. X-1. [pmid: 11689092].
1560 Silver JM, McAllister TW, Arciniegas DB. Depression and cognitive complaints following mild traumatic brain injury. Am J Psychiatry. 06. 2009;166(6):653-61. X-1, X-2, X-4, X-5. [pmid: 19487401].
1561 Silver JM, Sandberg DP, Hales RE. New approaches in the pharmacotherapy of posttraumatic stress disorder. J Clin Psychiatry. 10. 1990;51(Suppl):33-8. discussion 44–6. X-1, X-2.
1562 Silver JM, Yudofsky SC, Hales RE. Depression in traumatic brain injury. Neuropsychiatry, Neuropsychology, & Behavioral Neurology. Spr. 1991;4(1):12-23. X-1, X-2, X-4, X-5.
1563 Silverston P. Pulse oximetry at the roadside: a study of pulse oximetry in immediate care. BMJ. 03. 18. 1989;298(6675):711-3. X-1, X-5. [pmid: 2496817].
1564 Simic M, Draskovic D, Stojiljkovic G, et al. The characteristics of head wounds inflicted by “humane killer” (captive-bolt gun)--a 15-year study. J Forensic Sci. 09. 2007;52(5):1182-5. X-1, X-3. [pmid: 17767661].
1565 Simon KB. Outpatient treatment for an adult with traumatic brain injury. American Journal of Occupational Therapy. 04. 1988;42(4):247-251. X-5. [pmid: 3369535].
1566 Simpson DM, Gracies JM, Yablon SA, et al. Botulinum neurotoxin versus tizanidine in upper limb spasticity: A placebo-controlled study. Journal of Neurology, Neurosurgery and Psychiatry. 2009;80(4):380-385. X-1.
1567 Simpson G, Franke B, Gillett L. Suicide prevention training outside the mental health service system: evaluation of a state-wide program in Australia for rehabilitation and disability staff in the field of traumatic brain injury. Crisis. 2007;28(1):35-43. X-1. [pmid: 17555031].
1568 Simpson G, Tate R. Suicidality after traumatic brain injury: demographic, injury and clinical correlates. Psychol Med. 05. 2002;32(4):687-97. X-1. [pmid: 12102383].
1569 Simpson G, Tate R. Clinical features of suicide attempts after traumatic brain injury. J Nerv Ment Dis. 10. 2005;193(10):680-5. X-5. [pmid: 16208164].
1570 Simpson G, Tate R. Suicidality in people surviving a traumatic brain injury: Prevalence, risk factors and implications for clinical management. Brain Injury. 2007;21(13–14):1335-1351. X-2, X-5. [pmid: 18066936].
1571 Simpson G, Winstanley J, Bertapelle T. Suicide prevention training after traumatic brain injury: evaluation of a staff training workshop. J Head Trauma Rehabil. 09–10. 2003;18(5):445-56. X-1. [pmid: 12973274].
1572 Sinacori DR. Depression in a brain-injured sample: An investigation of indicators on the Rorschach and MMPI-2. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2000;60(8-B). X-7.
1573 Singh RP, Hatton M, Sprich S, et al. Posttraumatic stress. Ophthalmology. 06. 2007;114(6):1238. X-1, X-5. [pmid: 17544795].
1574 Singhal S, Powles R, Treleaven J, et al. Allogeneic bone marrow transplantation for primary myelofibrosis. Bone Marrow Transplantation. 1995;16(6):743-746. X-1, X-5. [pmid: 8750263].
1575 Sisler GC. Psychiatric aspects of the long-term course of severe diffuse non-progressive cerebral disease in adults. Can Psychiatr Assoc J. 06. 1968;13(3):211-7. X-1, X-5. [pmid: 5661686].
1576 Skell RL, Johnstone B, Schopp L, et al. Neuropsychological predictors of distress following traumatic brain injury. Brain Inj. 08. 2000;14(8):705-12. X-1. [pmid: 10969888].
1577 Slachevsky A, Pena M, Perez C, et al. Neuroanatomical basis of behavioral disturbances in patients with prefrontal lesions. Biol Res. 2006;39(2):237-50. X-1, X-5. [pmid: 16874399].
1578 Slama F, Bellivier F, Henry C, et al. Bipolar patients with suicidal behavior: toward the identification of a clinical subgroup. J Clin Psychiatry. 08. 2004;65(8):1035-9. X-1. [pmid: 15323586].
1579 Slaughter J, Johnstone G, Petroski G, et al. The usefulness of the Brief Symptom Inventory in the neuropsychological evaluation of traumatic brain injury. Brain Inj. 02. 1999;13(2):125-30. X-1. [pmid: 10079957].
1580 Small JG. The six per second spike and wave--a psychiatric population study. Electroencephalogr Clin Neurophysiol. 06. 1968;24(6):561-8. X-1. [pmid: 4172740].
1581 Smedler AC, Nilsson C, Bolme P. Total body irradiation: a neuropsychological risk factor in pediatric bone marrow transplant recipients. Acta Paediatr. 03. 1995;84(3):325-30. X-1, X-3, X-5. [pmid: 7780257].
1582 Smith AC, Shah SA, Hudson AE, et al. A Bayesian statistical analysis of behavioral facilitation associated with deep brain stimulation. J Neurosci Methods. 10. 15. 2009;183(2):267-76. X-1. [pmid: 19576932].
1583 Smith CG, Veenhuis PE, Meyer RE. Traumatic brain injury. North Carolina’s challenge. N C Med J. 11–12. 2001;62(6):328-34. X-1, X-2, X-4, X-5. [pmid: 11729460].
1584 Smith GA, Bowman MJ, Luria JW, et al. Babywalker-related injuries continue despite warning labels and public education. Pediatrics. 08. 1997;100(2):E1. X-1, X-3.
1585 Smith RB, Tiberi A, Marshall J. The use of cranial electrotherapy stimulation in the treatment of closed-head-injured patients. Brain Inj. 05–06. 1994;8(4):357-61. X-5. [pmid: 8081350].
1586 Soberg HL, Bautz-Holter E, Roise O, et al. Mental health and posttraumatic stress symptoms 2 years after severe multiple trauma: self-reported disability and psychosocial functioning. Arch Phys Med Rehabil. 03. 2010;91(3):481-8. X-1, X-5. [pmid: 20298843].
1587 Sockalingam S, Li M, Krishnadev U, et al. Use of animal-assisted therapy in the rehabilitation of an assault victim with a concurrent mood disorder. Issues in Mental Health Nursing. 01. 2008;29(1):73-84. X-5. [pmid: 18214780].
1588 Solheim O, Skeidsvoll T. Transient global amnesia may be caused by cerebral vein thrombosis. Medical Hypotheses. 2005;65(6):1142-1149. X-1. [pmid: 16061328].
1589 Sorensen PS, Gjerris A, Hammer M. Cerebrospinal fluid vasopressin in neurological and psychiatric disorders. Journal of Neurology, Neurosurgery & Psychiatry. 1985;48(1):50-57. X-1.
1590 Soto-Ares G, Vinchon M, Delmaire C, et al. Cerebellar atrophy after severe traumatic head injury in children. Childs Nerv Syst. 04. 2001;17(4–5):263-9. X-1, X-3, X-5. [pmid: 11398947].
1591 Soustiel JF, Glenn TC, Shik V, et al. Monitoring of cerebral blood flow and metabolism in traumatic brain injury. J Neurotrauma. 09. 2005;22(9):955-65. X-1. [pmid: 16156711].
1592 Soustiel JF, Sviri GE. Monitoring of cerebral metabolism: non-ischemic impairment of oxidative metabolism following severe traumatic brain injury. Neurol Res. 10. 2007;29(7):654-60. X-1. [pmid: 18173902].
1593 Southam JC, Gould JF. Chordoma, masquerading as a depressed fracture of the zygoma. Br J Oral Surg. 07. 1972;10(1):18-23. X-1. [pmid: 4506805].
1594 Soysal S, Topacoglu H, Karcioglu O, et al. Analysis of factors affecting pain in intravenous catheter placement: a survey of 925 patients. Int J Clin Pract. 06. 2005;59(6):675-9. X-1. [pmid: 15924596].
1595 Soysal S, Topacoglu H, Karcioglu O, et al. Factors affecting pain in intravenous catheter placement: role of depression illness. Int J Clin Pract. 03. 2005;59(3):276-80. X-1. [pmid: 15857322].
1596 Sparshatt A, Whiskey E, Taylor D. Valproate as prophylaxis for clozapine-induced seizures: Survey of practice. Psychiatric Bulletin. 2008;32(7):262-265. X-1, X-2.
1597 Spatt J, Zebenholzer K, Oder W. Psychosocial long-term outcome of severe head injury as perceived by patients, relatives, and professionals. Acta Neurol Scand. 03. 1997;95(3):173-9. X-5. [pmid: 9088387].
1598 Spence SE, Godfrey HP, Knight RG, et al. First impressions count: a controlled investigation of social skill following closed head injury. Br J Clin Psychol. 09. 1993;32(Pt 3):309-18. X-5. [pmid: 8251961].
1599 Spiers MV, Pouk JA, Santoro JM. Examining perspective-taking in the severely headinjured. Brain Inj. 07. 1994;8(5):463-73. X-1, X-5. [pmid: 7951209].
1600 Spinella M, Eaton LA. Hypomania induced by herbal and pharmaceutical psychotropic medicines following mild traumatic brain injury. Brain Injury. 04. 2002;16(4):359-367. X-5. [pmid: 11953006].
1601 Spitzer C, Vogel M, Barnow S, et al. Psychopathology and alexithymia in severe mental illness: the impact of trauma and posttraumatic stress symptoms. Eur Arch Psychiatry Clin Neurosci. 06. 2007;257(4):191-6. X-1. [pmid: 17464547].
1602 Spunda C. Beta activity and older age. Electroencephalogr Clin Neurophysiol. 08. 1969;27(2):212. X-1. [pmid: 4184169].
1603 Stambrook M, Moore AD, Peters LC, et al. Head injury and spinal cord injury: differential effects on psychosocial functioning. J Clin Exp Neuropsychol. 07. 1991;13(4):521-30. X-1. [pmid: 1918283].
1604 Stancin T, Wade SL, Walz NC, et al. Traumatic brain injuries in early childhood: initial impact on the family. J Dev Behav Pediatr. 08. 2008;29(4):253-61. X-3. [pmid: 18454041].
1605 Staniloiu A, Bender A, Smolewska K, et al. Ganser syndrome with work-related onset in a patient with a background of immigration. Cognitive Neuropsychiatry. 05. 2009;14(3):180-198. X-5. [pmid: 19499385].
1606 Stanislav SW, Childs NL. Dystonia associated with sertraline. Journal of Clinical Psychopharmacology. 02. 1999;19(1):98-100. X-5. [pmid: 9934951].
1607 Starkstein SE, Fedoroff P, Berthier ML, et al. Manic-depressive and pure manic states after brain lesions. Biol Psychiatry. 01. 15. 1991;29(2):149-58. X-1, X-5. [pmid: 1995084].
1608 Starkstein SE, Lischinsky A. The phenomenology of depression after brain injury. NeuroRehabilitation. 2002;17(2):105-13. X-2. [pmid: 12082237].
1609 Starkstein SE, Pearlson GD, Boston J, et al. Mania after brain injury. A controlled study of causative factors. Arch Neurol. 10. 1987;44(10):1069-73. X-5. [pmid: 3632381].
1610 Stassen LF, McGuinness AJ. A simple method of plate fixation of fractures of the frontal bone. Br J Oral Maxillofac Surg. 12. 1999;37(6):438-9. X-1. [pmid: 10687901].
1611 Statman SH. The evolution of depression over the first two years post head trauma. Dissertation Abstracts International. 1989;49(7-B). X-7.
1612 Steffens DC, Norton MC, Plassman BL, et al. Enhanced cognitive performance with estrogen use in nondemented community-dwelling older women. J Am Geriatr Soc. 10. 1999;47(10):1171-5. X-1. [pmid: 10522948].
1613 Steiger HJ, Aaslid R, Stooss R, et al. Transcranial Doppler monitoring in head injury: relations between type of injury, flow velocities, vasoreactivity, and outcome. Neurosurgery. 01. 1994;34(1):79-85. discussion 85–6. X-1. [pmid: 7907170].
1614 Stein J. What football tells us about everyday fitness, Los Angeles Times -- Southern California Edition. 06. 2. 2003:F1. F7. X-2.
1615 Stein SC, Ross SE. Moderate head injury: a guide to initial management. J Neurosurg. 10. 1992;77(4):562-4. X-1. [pmid: 1527615].
1616 Steinbok P, Flodmark O, Martens D, et al. Management of simple depressed skull fractures in children. J Neurosurg. 04. 1987;66(4):506-10. X-1, X-3. [pmid: 3559717].
1617 Stelmack JA, Frith T, Van Koevering D, et al. Visual function in patients followed at a Veterans Affairs polytrauma network site: an electronic medical record review. Optometry. 08. 2009;80(8):419-24. X-1. [pmid: 19635432].
1618 Stenback A, Achte KA, Rimon RH. Physical disease, hypochondria, and alcohol addiction in suicides committed by mental hospital patients. Br J Psychiatry. 10. 1965;111(479):933-7. X-1. [pmid: 5833605].
1619 Stephane M, Hill T, Matthew E, et al. New phenomenon of abnormal auditory perception associated with emotional and head trauma: Pathological confirmation by SPECT scan. Brain & Language. 2004;89(3):503-507. X-1, X-5. [pmid: 15120541].
1620 Stern B, Stern JM. Neuropsychological outcome during late stage of recovery from brain injury: a proposal. Scand J Rehabil Med Suppl. 1985;12:27-30. X-1, X-2, X-4, X-5. [pmid: 3868043].
1621 Stern JM, Melamed S, Silberg S, et al. Behavioral disturbances as an expression of severity of cerebral damage. Scand J Rehabil Med Suppl. 1985;12:36-41. X-1. [pmid: 3868045].
1622 Sterr A, Herron KA, Hayward C, et al. Are mild head injuries as mild as we think? Neurobehavioral concomitants of chronic post-concussion syndrome. BMC Neurol. 2006;6:7. X-1, X-5. [pmid: 16460567].
1623 Steudel WI, Hacker H. Prognosis, incidence and management of acute traumatic intracranial pneumocephalus. A retrospective analysis of 49 cases. Acta Neurochir (Wien). 1986;80(3–4):93-9. X-1, X-4. [pmid: 3716896].
1624 Steudel WI, Rosenthal D, Lorenz R, et al. Prognosis and treatment of cervical spine injuries with associated head trauma. Acta Neurochir Suppl (Wien). 1988;43:85-90. X-1. [pmid: 3213663].
1625 Stiefel DJ, Truelove EL, Persson RS, et al. A comparison of oral health in spinal cord injury and other disability groups. Spec Care Dentist. 11–12. 1993;13(6):229-35. X-1, X-5. [pmid: 8042130].
1626 Stilwell P, Stilwell J, Hawley C, et al. Measuring outcome in community-based rehabilitation services for people who have suffered traumatic brain injury: the Community Outcome Scale. Clin Rehabil. 12. 1998;12(6):521-31. X-1. [pmid: 9869256].
1627 Stippler M, Fischer MR, Puccio AM, et al. Serum and cerebrospinal fluid magnesium in severe traumatic brain injury outcome. J Neurotrauma. 08. 2007;24(8):1347-54. X-1. [pmid: 17711396].
1628 Stone IC. Characteristics of firearms and gunshot wounds as markers of suicide. Am J Forensic Med Pathol. 12. 1992;13(4):275-80. X-1. [pmid: 1288253].
1629 Stone JL, Hockley AD. Percivall Pott and the miners of Cornwall. Br J Neurosurg. 10. 2002;16(5):501-6. X-1, X-2, X-4, X-5. [pmid: 12498497].
1630 Street D, Burge S, Quadagno J. The effect of licensure type on the policies, practices, and resident composition of Florida assisted living facilities. Gerontologist. 04. 2009;49(2):211-23. X-1. [pmid: 19363016].
1631 Streeter CC, van Reekum R, Shorr RI, et al. Prior head injury in male veterans with borderline personality disorder. Journal of Nervous and Mental Disease. 09. 1995;183(9):577-581. X-1, X-5. [pmid: 7561819].
1632 Strom TQ, Kosciulek J. Stress, appraisal and coping following mild traumatic brain injury. Brain Inj. 10. 2007;21(11):1137-45. X-1. [pmid: 17952714].
1633 Strong AJ, Fabricius M, Boutelle MG, et al. Spreading and synchronous depressions of cortical activity in acutely injured human brain. Stroke. 12. 2002;33(12):2738-43. X-1, X-5. [pmid: 12468763].
1634 Struck TH. Jamais vu episodes in relationship to baclofen treatment: A case report. Archives of Physical Medicine and Rehabilitation. 2002;83(6):846-849. X-5. [pmid: 12048665].
1635 Subasi M, Arslan H, Necmioglu S, et al. Long-term outcomes of conservatively treated paediatric pelvic fractures. Injury. 08. 2004;35(8):771-81. X-3, X-5. [pmid: 15246800].
1636 Subczynski JA. One-stage debridement and plastic repair of compound comminuted depressed skull fractures with methyl methacrylate. J Trauma. 06. 1977;17(6):467-9. X-1, X-5. [pmid: 864800].
1637 Suchy Y, Leahy B, Sweet JJ, et al. Behavioral Dyscontrol Scale deficits among traumatic brain injury patients, part II: Comparison to other measures of executive functioning. Clin Neuropsychol. 11. 2003;17(4):492-506. X-5. [pmid: 15168914].
1638 Sugarman N, David TJ. Criminal injuries compensation for abused children. Arch Dis Child. 04. 2004;89(4):300-2. X-1. [pmid: 15033834].
1639 Suhr J, Tranel D, Wefel J, et al. Memory performance after head injury: contributions of malingering, litigation status, psychological factors, and medication use. J Clin Exp Neuropsychol. 08. 1997;19(4):500-14. X-1. [pmid: 9342686].
1640 Suhr JA, Gunstad J. Postconcussive symptom report: the relative influence of head injury and depression. J Clin Exp Neuropsychol. 12. 2002;24(8):981-93. X-1. [pmid: 12650225].
1641 Suhr JA, Gunstad J. Further exploration of the effect of “diagnosis threat” on cognitive performance in individuals with mild head injury. J Int Neuropsychol Soc. 01. 2005;11(1):23-9. X-1. [pmid: 15686605].
1642 Sullivan MJL, Thibault P, Simmonds MJ, et al. Pain, perceived injustice and the persistence of post-traumatic stress symptoms during the course of rehabilitation for whiplash injuries. Pain. 10. 2009;145(3):325-331. X-1. [pmid: 19643543].
1643 Sulton LL. Brain injury: a primary-care perspective. Clinical Advisor for Nurse Practitioners. 07. 87. 2007;10(7):84-9. X-1, X-2, X-4, X-5.
1644 Sumpter RE, McMillan TM. Misdiagnosis of post-traumatic stress disorder following severe traumatic brain injury. Br J Psychiatry. 05. 2005;186:423-6. X-1, X-5. [pmid: 15863748].
1645 Sun M, Zhan XP, Jin CY, et al. Clinical observation on treatment of post-craniocerebral traumatic mental disorder by integrative medicine. Chin J Integr Med. 06. 2008;14(2):137-41. X-1. [pmid: 18679606].
1646 Sundstrom A, Nilsson LG, Cruts M, et al. Fatigue before and after mild traumatic brain injury: pre-post-injury comparisons in relation to Apolipoprotein E. Brain Inj. 09. 2007;21(10):1049-54. X-6. [pmid: 17891567].
1647 Sunnybrook Health Sciences Centre, Ontario Mental Health Foundation. Depression and Traumatic Brain Injury, ClinicalTrials.gov. [Internet]. 2008. 2010. 02. 8. Feb 5. X-7.
1648 Susman M, DiRusso SM, Sullivan T, et al. Traumatic brain injury in the elderly: increased mortality and worse functional outcome at discharge despite lower injury severity. J Trauma. 08. 2002;53(2):219-23. discussion 223–4. X-1. [pmid: 12169925].
1649 Suwanjutha T. Direction, site and the muzzle target distance of bullet in the head and neck at close range as an indication of suicide or homicide. Forensic Sci Int. 05. 1988;37(3):223-9. X-1. [pmid: 3402862].
1650 Svendsen H, Teasdale T, Pinner M. Subjective experience in patients with brain injury and their close relatives before and after a rehabilitation programme. Neuropsychological Rehabilitation: An International Journal. 2004;14(5):495-515. X-1.
1651 Svendsen HA, Teasdale TW. The influence of neuropsychological rehabilitation on symptomatology and quality of life following brain injury: a controlled long-term followup. Brain Inj. 11. 2006;20(12):1295-306. X-1. [pmid: 17132552].
1652 Swann AC, Gerard Moeller F, Steinberg JL, et al. Manic symptoms and impulsivity during bipolar depressive episodes. Bipolar Disord. 05. 2007;9(3):206-12. X-1, X-5. [pmid: 17430294].
1653 Swearer JM, O’Donnell BF, Parker M, et al. Psychological features in persons at risk for familial Alzheimer’s disease. Am J Alzheimers Dis Other Demen. 05–06. 2001;16(3):157-62. X-1, X-5. [pmid: 11398564].
1654 Tadir M, Stern JM. The mourning process with brain injured patients. Scand J Rehabil Med Suppl. 1985;12:50-2. X-1, X-2, X-4, X-5. [pmid: 3868049].
1655 Takebayashi H, Takei N, Mori N, et al. Unilateral auditory hallucinations in schizophrenia after damage to the right hippocampus. Schizophrenia Research. 12. 2002;58(2–3):329-331. X-1, X-5. [pmid: 12409174].
1656 Talamonti G, Fontana R, Villa F, et al. “High risk” anterior basal skull fractures. Surgical treatment of 64 consecutive cases. J Neurosurg Sci. 09. 1995;39(3):191-7. X-1. [pmid: 8965129].
1657 Taleporos G, McCabe MP. The impact of sexual esteem, body esteem, and sexual satisfaction on psychological well-being in people with physical disability. Sexuality & Disability. 2002;20(3):177-83. X-1.
1658 Tan G, Fink B, Dao TK, et al. Associations among pain, PTSD, mTBI, and heart rate variability in veterans of Operation Enduring and Iraqi Freedom: a pilot study. Pain Med. 10. 2009;10(7):1237-45. X-1, X-5. [pmid: 19818034].
1659 Tan KL. Elevation of congenital depressed fractures of the skull by the vacuum extractor. Acta Paediatr Scand. 07. 1974;63(4):562-4. X-1. [pmid: 4851834].
1660 Tan XH. Risk factors for Parkinson disease and the path analysis: One-to-one paired design. Neural Regeneration Research. 2007;2(2):117-120. X-1.
1661 Tanaka A, Kimura M, Yoshinaga S, et al. Quantitative electroencephalographic correlates of cerebral blood flow in patients with chronic subdural hematomas. Surg Neurol. 09. 1998;50(3):235-40. X-1, X-5. [pmid: 9736086].
1662 Tanaka A, Nakayama Y, Yoshinaga S. Cerebral blood flow and intracranial pressure in chronic subdural hematomas. Surg Neurol. 04. 1997;47(4):346-51. X-1, X-5. [pmid: 9122837].
1663 Tanaka S, Takeuchi S, Ideta H. Ultrasound biomicroscopy for detection of breaks and detachment of the ciliary epithelium. Am J Ophthalmol. 10. 1999;128(4):466-71. X-1, X-5. [pmid: 10577587].
1664 Tanielian TL, Jaycox L. Invisible wounds of war psychological and cognitive injuries, their consequences, and services to assist recovery. Internet Resource; Computer File Date of Entry: 20080711. 2008;xliii:453. ill. (charts); 26 cm. X-7.
1665 Tate R, Simpson G, Flanagan S, et al. Completed suicide after traumatic brain injury. Journal of Head Trauma Rehabilitation. 1997;12(6):16-28. X-1, X-5.
1666 Tateno A, Murata Y, Robinson RG. Comparison of cognitive impairment associated with major depression following stroke versus traumatic brain injury. Psychosomatics. 07–08. 2002;43(4):295-301. X-1. [pmid: 12189255].
1667 Tator CH, Fleming JF, Sheppard RH, et al. Studies of cerebrospinal fluid dynamics with intrathecally administered radioiodinated human serum albumin (131-IHSA). Can Med Assoc J. 09. 2. 1967;97(10):493-503. X-1. [pmid: 6071789].
1668 Tatrow K, Blanchard EB, Hickling EJ, et al. Posttraumatic headache: biopsychosocial comparisons with multiple control groups. Headache. 07–08. 2003;43(7):755-66. X-1. [pmid: 12890130].
1669 Taylor AE, Cox CA, Mailis A. Persistent neuropsychological deficits following whiplash: evidence for chronic mild traumatic brain injury. Arch Phys Med Rehabil. 06. 1996;77(6):529-35. X-5. [pmid: 8831467].
1670 Taylor CA, Saint-Hilaire MH, Cupples LA, et al. Environmental, medical, and family history risk factors for Parkinson’s disease: a New England-based case control study. Am J Med Genet. 12. 15. 1999;88(6):742-9. X-1. [pmid: 10581500].
1671 Taylor JV, Gordon LE, Hall H, et al. Differences between bacterial species shown by simultaneous assessment of neutrophil phagocytosis and generation of reactive oxygen intermediates in trauma patients. Arch Surg. 11. 1999;134(11):1222-7. discussion 1227–8. X-1, X-5. [pmid: 10555637].
1672 Taylor R, O’Carroll R. Cognitive estimation in neurological disorders. Br J Clin Psychol. 05. 1995;34(Pt 2):223-8. X-1. [pmid: 7647713].
1673 Teasdale TW, Engberg AW. Suicide after traumatic brain injury: a population study. J Neurol Neurosurg Psychiatry. 10. 2001;71(4):436-40. X-1, X-4. [pmid: 11561024].
1674 Teive HA, Kowacs PA, Maranhao Filho P, et al. Leao’s cortical spreading depression: from experimental “artifact” to physiological principle. Neurology. 11. 8. 2005;65(9):1455-9. X-1. [pmid: 16275835].
1675 Temkin NR. Risk factors for posttraumatic seizures in adults. Epilepsia. 2003;44(Suppl 10):18-20. X-1, X-2. [pmid: 14511390].
1676 Tenovuo O. Central acetylcholinesterase inhibitors in the treatment of chronic traumatic brain injury - Clinical experience in 111 patients. Progress in Neuro Psychopharmacology & Biological Psychiatry. 2005;29(1):61-67. X-1. [pmid: 15610946].
1677 Tenovuo O, Alin J, Helenius H. A randomized controlled trial of rivastigmine for chronic sequels of traumatic brain injury - What it showed and taught. Brain Injury. 2009;23(6):548-558. X-1. [pmid: 19484628].
1678 Terndrup TE, Cantor RM, Madden CM. Intramuscular meperidine, promethazine, and chlorpromazine: analysis of use and complications in 487 pediatric emergency department patients. Ann Emerg Med. 05. 1989;18(5):528-33. X-1, X-3. [pmid: 2719364].
1679 Tesio L. Measuring behaviours and perceptions: Rasch analysis as a tool for rehabilitation research. J Rehabil Med. 05. 2003;35(3):105-15. X-1, X-2, X-4, X-5. [pmid: 12809192].
1680 Testa JA, Malec JF, Moessner AM, et al. Predicting family functioning after TBI: impact of neurobehavioral factors. J Head Trauma Rehabil. 05–06. 2006;21(3):236-47. X-1. [pmid: 16717501].
1681 Thaut MH, Gardiner JC, Holmberg D, et al. Neurologic music therapy improves executive function and emotional adjustment in traumatic brain injury rehabilitation. Ann N Y Acad Sci. 07. 2009;1169:406-16. X-1, X-5. [pmid: 19673815].
1682 Thaut MH, Gardiner JC, Holmberg D, et al. Neurologic Music Therapy Improves Executive Function and Emotional Adjustment in Traumatic Brain Injury Rehabilitation. Neurosciences and Music III: Disorders and Plasticity. 2009:406-416. X-7.
1683 Thomsen IV. Late psychosocial outcome in severe traumatic brain injury. Preliminary results of a third follow-up study after 20 years. Scand J Rehabil Med Suppl. 1992;26:142-52. X-1, X-5. [pmid: 1488637].
1684 Thoresen S. Fatal head injuries from firearms. An autopsy study of 270 cases. Z Rechtsmed. 1984;93(2):65-9. X-1. [pmid: 6516602].
1685 Thornbury JR, Campbell JA, Masters SJ, et al. Skull fracture and the low risk of intracranial sequelae in minor head trauma. AJR Am J Roentgenol. 09. 1984;143(3):661-4. X-1. [pmid: 6331755].
1686 Thorne FC, Nathan PE. The general validity of official diagnostic classifications. J Clin Psychol. 10. 1969;25(4):375-82. X-1. [pmid: 5809413].
1687 Tiersky LA, Anselmi V, Johnston MV, et al. A trial of neuropsychologic rehabilitation in mild-spectrum traumatic brain injury. Arch Phys Med Rehabil. 08. 2005;86(8):1565-74. X-5. [pmid: 16084809].
1688 Tiller SG, Persinger MA. Test-retest scores for patients who display neuropsychological impairment following “mild head injuries” from mechanical impacts. Percept Mot Skills. 06. 1998;86(3 Pt 2):1240-2. X-5. [pmid: 9700799].
1689 Timming R, Orrison WW, Mikula JA. Computerized tomography and rehabilitation outcome after severe head trauma. Arch Phys Med Rehabil. 04. 1982;63(4):154-9. X-5. [pmid: 7082137].
1690 Timonen M, Miettunen J, Hakko H, et al. The association of preceding traumatic brain injury with mental disorders, alcoholism and criminality: the Northern Finland 1966 Birth Cohort Study. Psychiatry Res. 12. 30. 2002;113(3):217-26. X-1. [pmid: 12559478].
1691 Tisdall MM, Tachtsidis I, Leung TS, et al. Increase in cerebral aerobic metabolism by normobaric hyperoxia after traumatic brain injury. J Neurosurg. 09. 2008;109(3):424-32. X-1, X-5. [pmid: 18759572].
1692 Tobias ES, Brodie AF, Brodie MJ. An outcome audit at the epilepsy clinic: Results from 1000 consecutive referrals. Seizure. 1994;3(1):37-43. X-1, X-4. [pmid: 8044452].
1693 Todd EM, Crue BL Jr. Depressed fractures of the skull in infants. Surgical management. Am J Surg. 04. 1967;113(4):479-81. X-1. [pmid: 6023018].
1694 Todd J, Coolidge F, Satz P. The Wechsler Adult Intelligence Scale discrepancy index: a neuropsychological evaluation. J Consult Clin Psychol. 06. 1977;45(3):450-4. X-1. [pmid: 864059].
1695 Tomei G, Gaini SM, Giovanelli M, et al. Traumatic brain lacerations in children: surgical results and follow-up. Childs Brain. 1981;8(6):434-43. X-1, X-3. [pmid: 6796341].
1696 Tomic Z, Pavlovic S, Latinovic S. Surgical treatment of penetrating ocular injuries with retained intraocular foreign bodies. Eur J Ophthalmol. 07–09. 1996;6(3):322-6. X-1, X-5. [pmid: 8908441].
1697 Tonks A. Short cuts: all you need to read in the other general journals. BMJ British Medical Journal. 03. 7. 2009;338(7694):566-7. X-2.
1698 Toronto Rehabilitation Institute Ontario Neurotrauma Foundation Peel Halton Acquired Brain Injury Services. Improving Psychological Wellness After Acquired Brain Injury, ClinicalTrials.gov. [Internet]. 2009. 2010. 02. 8. Feb 5. X-7.
1699 Torsney K. The need to explore the prevalence and treatment of acquired brain injury among persons with serious and persistent mental illnesses. Psychiatr Rehabil J. Summer. 2004;28(1):75-7. X-1, X-2, X-4, X-5. [pmid: 15468641].
1700 Tottene A, Pivotto F, Fellin T, et al. Specific kinetic alterations of human CaV2.1 calcium channels produced by mutation S218L causing familial hemiplegic migraine and delayed cerebral edema and coma after minor head trauma. J Biol Chem. 05. 6. 2005;280(18):17678-86. X-1, X-3, X-5. [pmid: 15743764].
1701 Towbin A. The depressed newborn: pathogenesis and neurologic sequels. Perinatology Neonatology. 05–06. 1987;11(3):16-8. X-1.
1702 Traeger SM, Henning RJ, Dobkin W, et al. Hemodynamic effects of pentobarbital therapy for intracranial hypertension. Crit Care Med. 09. 1983;11(9):697-701. X-1. [pmid: 6884049].
1703 Trahan DE, Ross CE, Trahan SL. Relationships among postconcussional-type symptoms, depression, and anxiety in neurologically normal young adults and victims of mild brain injury. Archives of Clinical Neuropsychology. 07. 2001;16(5):435-445. X-1, X-5. [pmid: 14590158].
1704 Trethowan WH. Rehabilitation of the brain injured: the psychiatric angle. Proc R Soc Med. 01. 1970;63(1):32-6. X-1. [pmid: 5417768].
1705 Trudeau DL, Anderson J, Hansen LM, et al. Findings of mild traumatic brain injury in combat veterans with PTSD and a history of blast concussion. J Neuropsychiatry Clin Neurosci. Summer. 1998;10(3):308-13. X-1. [pmid: 9706538].
1706 Tsai L, Tsuang MT. How can we avoid unnecessary CT scanning for psychiatric patients. J Clin Psychiatry. 12. 1981;42(12):452-4. X-1. [pmid: 7309687].
1707 Tsaousides T, Ashman T, Seter C. The psychological effects of employment after traumatic brain injury: Objective and subjective indicators. Rehabilitation Psychology. 11. 2008;53(4):456-463. X-1.
1708 Tsiantis J. The preventive effect of early interventions. Bibl Psychiatr. 1994;(165):26-30. X-1, X-2, X-4, X-5. [pmid: 7993359].
1709 Tsiouris JA. Pharmacotherapy for aggressive behaviours in persons with intellectual disabilities: Treatment or mistreatment. Journal of Intellectual Disability Research. 2010;54(1):1-16. X-1, X-2. [pmid: 20122096].
1710 Tsolaki M, Fountoulakis K, Chantzi E, et al. Risk factors for clinically diagnosed Alzheimer’s disease: a case-control study of a Greek population. Int Psychogeriatr. 09. 1997;9(3):327-41. X-1. [pmid: 9513031].
1711 Tucker K, Lettin A. The Tower of London bomb explosion. Br Med J. 08. 2. 1975;3(5978):287-90. X-1, X-4, X-5. [pmid: 1148778].
1712 Tufo HM, Muslin H, Ostfeld AM. Central nervous system complications in the surgical patient. Diagnosis and management. Dis Mon. 11. 1968:1-30. X-1, X-2, X-5.
1713 Turk EE, Tsokos M. Pathologic features of fatal falls from height. Am J Forensic Med Pathol. 09. 2004;25(3):194-9. X-1, X-3. [pmid: 15322459].
1714 Turnbull SJ, Campbell EA, Swann IJ. Post-traumatic stress disorder symptoms following a head injury: does amnesia for the event influence the development of symptoms. Brain Inj. 09. 2001;15(9):775-85. X-1. [pmid: 11516346].
1715 Turner B, Fleming J, Cornwell P, et al. Profiling early outcomes during the transition from hospital to home after brain injury. Brain Inj. 01. 2009;23(1):51-60. X-1, X-5. [pmid: 19172450].
1716 Turner B, Fleming J, Cornwell P, et al. A qualitative study of the transition from hospital to home for individuals with acquired brain injury and their family caregivers. Brain Inj. 10. 2007;21(11):1119-30. X-5. [pmid: 17952712].
1717 Turner-Stokes L, Hassan N, Pierce K, et al. Managing depression in brain injury rehabilitation: the use of an integrated care pathway and preliminary report of response to sertraline. Clin Rehabil. 05. 2002;16(3):261-8. X-1. [pmid: 12017513].
1718 Turner-Stokes L, Kalmus M, Hirani D, et al. The Depression Intensity Scale Circles (DISCs): a first evaluation of a simple assessment tool for depression in the context of brain injury. J Neurol Neurosurg Psychiatry. 09. 2005;76(9):1273-8. X-1. [pmid: 16107367].
1719 Tyerman A, Humphrey M. Changes in self-concept following severe head injury. Int J Rehabil Res. 03. 1984;7(1):11-23. X-5. [pmid: 6735545].
1720 Tyrrell J, Cosgrave M, McCarron M, et al. Dementia in people with Down’s syndrome. Int J Geriatr Psychiatry. 12. 2001;16(12):1168-74. X-1. [pmid: 11748777].
1721 Ukpong DI, Ugboko VI, Ndukwe KC, et al. Psychological complications of maxillofacial trauma: preliminary findings from a Nigerian university teaching hospital. J Oral Maxillofac Surg. 05. 2007;65(5):891-4. X-1, X-5. [pmid: 17448838].
1722 Ukpong DI, Ugboko VI, Ndukwe KC, et al. Health-related quality of life in Nigerian patients with facial trauma and controls: a preliminary survey. Br J Oral Maxillofac Surg. 06. 2008;46(4):297-300. X-1, X-5. [pmid: 18336970].
1723 Ulvik A, Kvale R, Wentzel-Larsen T, et al. Quality of life 2–7 years after major trauma. Acta Anaesthesiol Scand. 02. 2008;52(2):195-201. X-1. [pmid: 18005377].
1724 Umansky R, Geller V. Olanzapine treatment in an organic hallucinosis patient. International Journal of Neuropsychopharmacology. 03. 2000;3(1):81-82. X-5. [pmid: 11343582].
1725 Underhill AT, Lobello SG, Stroud TP, et al. Depression and life satisfaction in patients with traumatic brain injury: a longitudinal study. Brain Inj. 11. 2003;17(11):973-82. X-6. [pmid: 14514448].
1726 Ungerstedt U. Adipsia and aphagia after 6-hydroxydopamine induced degeneration of the nigro-striatal dopamine system. Acta Physiol Scand Suppl. 1971;367:95-122. X-1. [pmid: 4332694].
1727 University of Illinois at Chicago. Neuropsychiatry of traumatic brain injury 2008 2008. 2010. 02. 8. Feb 5. X-7.
1728 University of Iowa, National Institute of Neurological Disorders and Stroke (NINDS). Treatment Strategy to Prevent Mood Disorders Following Traumatic Brain Injury, ClinicalTrials.gov. [Internet]. 2008. 2010. 02. 8. Feb 5. X-7.
1729 University of Iowa NIoNDaSN. Treatment strategy to prevent mood disorders following traumatic brain injury. 2008 2009. 2010. 02. 8. Feb 5. X-7.
1730 University of Washington. Telephone and In-Person Cognitive Behavioral Therapy for Depression After Traumatic Brain Injury. 2007 October 1, 2007. 2010. 02. 8. Feb 5. X-7.
1731 University of Washington. The Effect of Exercise on Mood After Traumatic Brain Injury, ClinicalTrials.gov. [Internet]. 2008. 2010. 02. 8. Feb 5. X-7.
1732 University of Washington. Phone cognitive behavioral therapy for depression after traumatic brain injury. 2008 2008. 2010. 02. 8. Feb 5. X-7.
1733 Urbach A, Redecker C, Witte OW. Induction of neurogenesis in the adult dentate gyrus by cortical spreading depression. Stroke. 11. 2008;39(11):3064-72. X-1, X-3. [pmid: 18802207].
1734 Uysal S, Hibbard MR, Robillard D, et al. The effect of parental traumatic brain injury on parenting and child behavior. J Head Trauma Rehabil. 12. 1998;13(6):57-71. X-5. [pmid: 9885318].
1735 Uzun I, Buyuk Y, Erkol Z, et al. Fatalities caused by spherical bullets fired from blank cartridge guns in Istanbul, Turkey. J Forensic Sci. 09. 2009;54(5):1127-30. X-1. [pmid: 19570048].
1736 Vajkoczy P, Schurer L, Munch E, et al. Penetrating craniocerebral injuries in a civilian population in mid-Europe. Clin Neurol Neurosurg. 09. 1999;101(3):175-81. X-5. [pmid: 10536903].
1737 Vale FA, Miranda SJ. Clinical and demographic features of patients with dementia attended in a tertiary outpatient clinic. Arq Neuropsiquiatr. 09. 2002;60(3-A):548-52. X-1. [pmid: 12244388].
1738 Valera EM, Berenbaum H. Brain injury in battered women. J Consult Clin Psychol. 08. 2003;71(4):797-804. X-1. [pmid: 12924684].
1739 Van Den Eeden SK, Tanner CM, Popat RA, et al. The risk of Parkinson’s disease associated with head injury and depression: A population-based case-control study. Neurology. [Meeting]. 04. 11. 2000;54(7 Supp 3):A347. X-7.
1740 van den Heever CM, van der Merwe DJ. Management of depressed skull fractures. Selective conservative management of nonmissile injuries. J Neurosurg. 08. 1989;71(2):186-90. X-1. [pmid: 2501461].
1741 van der Naalt J, van Zomeren AH, Sluiter WJ, et al. Acute behavioural disturbances related to imaging studies and outcome in mild-to-moderate head injury. Brain Inj. 09. 2000;14(9):781-8. X-1. [pmid: 11030452].
1742 van Dijk-Milatz A. Total-body irradiation in advanced lymphosarcoma. Br J Radiol. 07. 1979;52(619):568-70. X-1, X-5. [pmid: 111751].
1743 Van Enk A. Letter: Reduction of pond depressed fractures by vacuum extraction. Trop Doct. 01. 1974;4(1):47-8. X-1. [pmid: 4821285].
1744 van Huffelen AC, Magnus O. 4 C-sex vertex spindles. Electroencephalogr Clin Neurophysiol. 05. 1973;34(5):543-6. X-1. [pmid: 4121326].
1745 Van Lancker D, Sidtis JJ. The identification of affective-prosodic stimuli by left- and right-hemisphere-damaged subjects: all errors are not created equal. J Speech Hear Res. 10. 1992;35(5):963-70. X-1, X-5. [pmid: 1447930].
1746 Van Mier H, Hulstijn W, Tromp E, et al. Fine motor performance in closed head injury and depression. Society for Neuroscience Abstracts [Meeting]. 1990;16(2):1317. X-7.
1747 van Reekum R, Bolago I, Finlayson MA, et al. Psychiatric disorders after traumatic brain injury. Brain Inj. 05. 1996;10(5):319-27. X-5. [pmid: 8735663].
1748 van Zomeren AH, ten Duis H-J, Minderhoud JM, et al. Lightning stroke and neuropsychological impairment: Cases and questions. Journal of Neurology, Neurosurgery & Psychiatry. 06. 1998;64(6):763-770. X-3, X-5.
1749 Vanamo T, Kauppi A, Karkola K, et al. Intra-familial child homicide in Finland 1970–1994 incidence, causes of death and demographic characteristics. Forensic Sci Int. 04. 1. 2001;117(3):199-204. X-1, X-3. [pmid: 11248450].
1750 Vanderploeg RD, Belanger HG, Curtiss G. Mild traumatic brain injury and posttraumatic stress disorder and their associations with health symptoms. Arch Phys Med Rehabil. 07. 2009;90(7):1084-93. X-1. [pmid: 19577020].
1751 Vanderploeg RD, Curtiss G, Duchnick JJ, et al. Demographic, medical, and psychiatric factors in work and marital status after mild head injury. J Head Trauma Rehabil. 03–04. 2003;18(2):148-63. X-1. [pmid: 12802224].
1752 Vanderploeg RD, Curtiss G, Luis CA, et al. Long-term morbidities following selfreported mild traumatic brain injury. J Clin Exp Neuropsychol. 08. 2007;29(6):585-98. X-1. [pmid: 17691031].
1753 Vapalahti M, Luukkonen M, Puranen M, et al. Early clinical signs and prognosis in children with brain injuries. Ann Clin Res. 1986;18(Suppl 47):37-42. X-1, X-3. [pmid: 3101575].
1754 Varma RS, Shirey RE, Varma R. Glycosaminoglycan levels in sera of patients with mental disorders. Biochem Exp Biol. 1980;16(4):431-5. X-1, X-5. [pmid: 7346061].
1755 Varoglu AO, Saygi S, Acemoglu H, et al. Prognosis of patients with mesial temporal lobe epilepsy due to hippocampal sclerosis. Epilepsy Research. 2009;85(2–3):206-211. X-1. [pmid: 19345070].
1756 Vas CJ, Exley KA, Parsonage MJ. Activation of the EEG by procyclidine hydrochloride in temporal lobe epilepsy. Epilepsia. 12. 1967;8(4):241-51. X-1. [pmid: 5238716].
1757 Vasconez HC, Shockley ME, Luce EA. High-energy gunshot wounds to the face. Ann Plast Surg. 01. 1996;36(1):18-25. X-1, X-5. [pmid: 8722979].
1758 Vassallo JL, Proctor-Weber Z, Lebowitz BK, et al. Psychiatric risk factors for traumatic brain injury. Brain Inj. 06. 2007;21(6):567-73. X-1, X-5. [pmid: 17577707].
1759 Vasterling JJ, Proctor SP, Amoroso P, et al. Neuropsychological outcomes of army personnel following deployment to the Iraq war. JAMA. 08. 2. 2006;296(5):519-29. X-1, X-2. [pmid: 16882958].
1760 Vatsavayi V, Malhotra S, Franco K. Agitated delirium with posterior cerebral artery infarction. Journal of Emergency Medicine. 2003;24(3):263-266. X-1. [pmid: 12676294].
1761 Veiel HO. A preliminary profile of neuropsychological deficits associated with major depression. J Clin Exp Neuropsychol. 08. 1997;19(4):587-603. X-1, X-2. [pmid: 9342691].
1762 Velakoulis D, Lloyd JH. The role of SPECT scanning in a neuropsychiatry unit. Aust N Z J Psychiatry. 08. 1998;32(4):511-22. X-1. [pmid: 9711365].
1763 Velly AM, Gornitsky M, Philippe P. A case-control study of temporomandibular disorders: symptomatic disc displacement. J Oral Rehabil. 05. 2002;29(5):408-16. X-1. [pmid: 12028486].
1764 Velly AM, Gornitsky M, Philippe P. Contributing factors to chronic myofascial pain: a case-control study. Pain. 08. 2003;104(3):491-9. X-1. [pmid: 12927621].
1765 Verma A, Anand V, Verma NP. Sleep disorders in chronic traumatic brain injury. J Clin Sleep Med. 06. 15. 2007;3(4):357-62. X-1. [pmid: 17694723].
1766 Vickery CD, Gontkovsky ST, Caroselli JS. Self-concept and quality of life following acquired brain injury: a pilot investigation. Brain Inj. 08. 20. 2005;19(9):657-65. X-5. [pmid: 16195178].
1767 Victoroff J. DSM-III--R psychiatric diagnoses in candidates for epilepsy surgery: Lifetime prevalence. Neuropsychiatry, Neuropsychology, & Behavioral Neurology. 04. 1994;7(2):87-97. X-1, X-5.
1768 Viguier D, Dellatolas G, Gasquet I, et al. A psychological assessment of adolescent and young adult inpatients after traumatic brain injury. Brain Inj. 03. 2001;15(3):263-71. X-4. [pmid: 11260774].
1769 Vilela T, Phillips M, Minnes P. A comparison of challenges faced by parents of children with ABI with and without access to third party funding. Dev Neurorehabil. 04–06. 2008;11(2):149-58. X-1. [pmid: 18415820].
1770 Vilensky JA, Foley P, Gilman S. Children and encephalitis lethargica: a historical review. Pediatr Neurol. 08. 2007;37(2):79-84. X-1, X-2, X-3. [pmid: 17675021].
1771 Vincentiis S, Valente KD, Thome-Souza S, et al. Risk factors for psychogenic nonepileptic seizures in children and adolescents with epilepsy. Epilepsy Behav. 02. 2006;8(1):294-8. X-1, X-3. [pmid: 16253566].
1772 Virginia Commonwealth University, U.S. Department of Education. Pharmacological Intervention in Depression After Traumatic Brain Injury, ClinicalTrials.gov. [Internet]. 2007. 2010. 02. 8. Feb 5. X-7.
1773 Vougiouklakis T, Tsiligianni C. Forensic and criminologic aspects of murder in North-West (Epirus) Greece. J Clin Forensic Med. 08–09. 2006;13(6–8):316-20. X-1, X-5. [pmid: 17029921].
1774 Vrankovic D, Glavina K. Cranioplasty of the anterior fossa traumatic bone defect using autologous cancellous bone. Neurochirurgia (Stuttg). 07. 1989;32(4):110-5. X-1, X-5. [pmid: 2671767].
1775 Vrankovic D, Splavski B, Hecimovic I, et al. Self-inflicted gunshot wounds to the head during the war and post-war period. Injury. 06. 1998;29(5):369-73. X-5. [pmid: 9813681].
1776 Wachter D, Gundling K, Oertel MF, et al. Pituitary insufficiency after traumatic brain injury. Journal of Clinical Neuroscience. 2009;16(2):202-208. X-6. [pmid: 19097906].
1777 Wade SL, Carey J, Wolfe CR. An online family intervention to reduce parental distress following pediatric brain injury. J Consult Clin Psychol. 06. 2006;74(3):445-54. X-3, X-5. [pmid: 16822102].
1778 Wade SL, Michaud L, Brown TM. Putting the pieces together: preliminary efficacy of a family problem-solving intervention for children with traumatic brain injury. J Head Trauma Rehabil. 01–02. 2006;21(1):57-67. X-1, X-3, X-5. [pmid: 16456392].
1779 Wade SL, Taylor HG, Drotar D, et al. Parent-adolescent interactions after traumatic brain injury: their relationship to family adaptation and adolescent adjustment. J Head Trauma Rehabil. 03–04. 2003;18(2):164-76. X-3. [pmid: 12802225].
1780 Wade SL, Walz NC, Carey JC, et al. Preliminary efficacy of a Web-based family problem-solving treatment program for adolescents with traumatic brain injury. J Head Trauma Rehabil. 11–12. 2008;23(6):369-77. X-3, X-5. [pmid: 19033829].
1781 Wade SL, Wolfe C, Brown TM, et al. Putting the pieces together: preliminary efficacy of a web-based family intervention for children with traumatic brain injury. J Pediatr Psychol. 07–08. 2005;30(5):437-42. X-3, X-5. [pmid: 15944171].
1782 Wadman MC, Muelleman RL. Domestic violence homicides: ED use before victimization. Am J Emerg Med. 11. 1999;17(7):689-91. X-1. [pmid: 10597091].
1783 Walker AE. Long term evaluation of the social and family adjustment to head injuries. Scand J Rehabil Med. 1972;4(1):5-8. X-1. [pmid: 4643595].
1784 Walker GC, Cardenas DD, Guthrie MR, et al. Fatigue and depression in brain-injured patients correlated with quadriceps strength and endurance. Arch Phys Med Rehabil. 06. 1991;72(7):469-72. X-5. [pmid: 2059118].
1785 Walker R, Cole JE, Logan TK, et al. Screening substance abuse treatment clients for traumatic brain injury: prevalence and characteristics. J Head Trauma Rehabil. 11–12. 2007;22(6):360-7. X-1. [pmid: 18025968].
1786 Walker R, Hiller M, Staton M, et al. Head injury among drug abusers: an indicator of cooccurring problems. J Psychoactive Drugs. 07–09. 2003;35(3):343-53. X-6. [pmid: 14621132].
1787 Walker WC, Seel RT, Curtiss G, et al. Headache after moderate and severe traumatic brain injury: a longitudinal analysis. Arch Phys Med Rehabil. 09. 2005;86(9):1793-800. X-1. [pmid: 16181945].
1788 Wallace CA, Bogner J. Awareness of deficits: emotional implications for persons with brain injury and their significant others. Brain Inj. 06. 2000;14(6):549-62. X-1. [pmid: 10887888].
1789 Wallace D. Improvised explosive devices and traumatic brain injury: The military experience in Iraq and Afghanistan. Australasian Psychiatry. 2009;17(3):218-224. X-2. [pmid: 19404818].
1790 Wallis H, Renneberg B, Ripper S, et al. Emotional distress and psychosocial resources in patients recovering from severe burn injury. J Burn Care Res. 09–10. 2006;27(5):734-41. X-1. [pmid: 16998408].
1791 Walsh ME, Macleod AD. Breath alcohol analysis in the Accident and Emergency Department. Injury. 07. 1983;15(1):62-6. X-1. [pmid: 6885151].
1792 Wang W, Wang YH, Fu XM, et al. Auditory evoked potentials and multiple personality measures in migraine and post-traumatic headaches. Pain. 02. 1999;79(2–3):235-42. X-1, X-5. [pmid: 10068169].
1793 Wani AA, Ramzan AU, Tariq R, et al. Head injury in children due to cricket ball scenario in developing countries. Pediatr Neurosurg. 2008;44(3):204-7. X-1, X-3, X-5. [pmid: 18334844].
1794 Warden DL, Dougherty DS, Quintero-Sheeley E, et al. Psychotic symptoms following moderate traumatic brain injury. Neurology. [Meeting]. 1994. 1994;44(4 SUPPL 2):A401. X-7.
1795 Warden DL, Gordon B, McAllister TW, et al. Guidelines for the pharmacologic treatment of neurobehavioral sequelae of traumatic brain injury. J Neurotrauma. 10. 2006;23(10):1468-501. X-1, X-2, X-4, X-5. [pmid: 17020483].
1796 Warden DL, Labbate LA, Salazar AM, et al. Posttraumatic stress disorder in patients with traumatic brain injury and amnesia for the event?. J Neuropsychiatry Clin Neurosci. Winter. 1997;9(1):18-22. X-5. [pmid: 9017524].
1797 Warner JS, Fenichel GM. Chronic post-traumatic headache often a myth. Neurology. 04. 1996;46(4):915-916. X-1, X-5. [pmid: 8780063].
1798 Warriner EM, Rourke BP, Velikonja D, et al. Subtypes of emotional and behavioural sequelae in patients with traumatic brain injury. J Clin Exp Neuropsychol. 10. 2003;25(7):904-17. X-1. [pmid: 13680439].
1799 Wassenberg R, Max JE, Koele SL, et al. Classifying psychiatric disorders after traumatic brain injury and orthopaedic injury in children: adequacy of K-SADS versus CBCL. Brain Inj. 04. 2004;18(4):377-90. X-3. [pmid: 14742151].
1800 Wasserman L, Shaw T, Vu M, et al. An overview of traumatic brain injury and suicide. Brain Injury. 10. 2008;22(11):811-819. X-2. [pmid: 18850340].
1801 Watanabe K, Miyazaki S, Hara K, et al. Neonatal EEG and computerized tomography. Neuropadiatrie. 11. 1979;10(4):348-60. X-1, X-3. [pmid: 583442].
1802 Watanabe Y, Shiel A, Asami T, et al. An evaluation of neurobehavioural problems as perceived by family members and levels of family stress 1–3 years following traumatic brain injury in Japan. Clin Rehabil. 04. 2000;14(2):172-7. X-1, X-5. [pmid: 10763794].
1803 Waterloo K, Ingebrigtsen T, Romner B. Neuropsychological function in patients with increased serum levels of protein S-100 after minor head injury. Acta Neurochir (Wien). 1997;139(1):26-31. discussion 31–2. X-5. [pmid: 9059708].
1804 Watt KJ, O’Carroll RE. Evaluating methods for estimating premorbid intellectual ability in closed head injury. J Neurol Neurosurg Psychiatry. 04. 1999;66(4):474-9. X-1. [pmid: 10201419].
1805 Watters DA. Skull trepanation in the Bismarck archipelago. P N G Med J. 03–06. 2007;50(1–2):20-4. X-1, X-2. [pmid: 19354008].
1806 Watts R, Perlesz A. Psychosocial outcome risk indicator: predicting psychosocial outcome following traumatic brain injury. Brain Inj. 02. 1999;13(2):113-24. X-5. [pmid: 10079956].
1807 Webb MG, O’Donnell MP, Draper RJ, et al. Brain-type creatine phosphokinase serum levels before and after ECT. Br J Psychiatry. 05. 1984;144:525-8. X-1, X-5. [pmid: 6733378].
1808 Webber RL, Folio J. Radiographic detectability of occipital and temporal-parietal fractures induced in cadaver heads. J Trauma. 02. 1976;16(2):115-24. X-1, X-5. [pmid: 1255825].
1809 Weber J, Czarnetzki A. Brief communication: neurotraumatological aspects of head injuries resulting from sharp and blunt force in the early medieval period of southwestern Germany. Am J Phys Anthropol. 04. 2001;114(4):352-6. X-1, X-5. [pmid: 11275964].
1810 Weddell RA, Leggett JA. Factors triggering relatives’ judgements of personality change after traumatic brain injury. Brain Inj. 11. 2006;20(12):1221-34. X-1, X-2. [pmid: 17132545].
1811 Weeks LE. Handling of nonsevere head injuries. JACEP. 07. 1979;8(7):257-60. X-1. [pmid: 449158].
1812 Weeks WB, Lushkov G, Nelson WA, et al. Characteristics of rural and urban cadaveric organ transplant donors and recipients. J Rural Health. Summer. 2006;22(3):264-8. X-1. [pmid: 16824173].
1813 Wegner RC. Spirituality and religion as predictors of mood and quality of life following traumatic brain injury. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2008;69(2-B). X-7.
1814 Wehman PH, Revell WG, Kregel J, et al. Supported employment: an alternative model for vocational rehabilitation of persons with severe neurologic, psychiatric, or physical disability. Arch Phys Med Rehabil. 02. 1991;72(2):101-5. X-1, X-5. [pmid: 1991008].
1815 Wei W, Sambamoorthi U, Crystal S, et al. Mental illness, traumatic brain injury, and medicaid expenditures. Arch Phys Med Rehabil. 05. 2005;86(5):905-11. X-1. [pmid: 15895335].
1816 Weiner MF, Vega G, Risser RC, et al. Apolipoprotein E epsilon 4, other risk factors, and course of Alzheimer’s disease. Biol Psychiatry. 03. 1. 1999;45(5):633-8. X-1. [pmid: 10088051].
1817 Weinfurt KP, Willke R, Glick HA, et al. Towards a composite scoring solution for the Neurobehavioral Functioning Inventory. Qual Life Res. 1999;8(1–2):17-24. X-1. [pmid: 10457735].
1818 Weinstein CS, Fucetola R, Mollica R. Neuropsychological issues in the assessment of refugees and victims of mass violence. Neuropsychology Review. 09. 2001;11(3):131-141. X-2. [pmid: 11795840].
1819 Weissman MM, John K, Merikangas KR, et al. Depressed parents and their children. General health, social, and psychiatric problems. Am J Dis Child. 08. 1986;140(8):801-5. X-1. [pmid: 3728409].
1820 Wellings PC. Detection and recognition of visual field defects resulting from lesions involving the visual pathways. Aust N Z J Ophthalmol. 11. 1989;17(4):331-5. X-1, X-5. [pmid: 2624722].
1821 Wells R, Dywan J, Dumas J. Life satisfaction and distress in family caregivers as related to specific behavioural changes after traumatic brain injury. Brain Inj. 12. 2005;19(13):1105-15. X-1. [pmid: 16286324].
1822 Wenz F, Steinvorth S, Lohr F, et al. Prospective evaluation of delayed central nervous system (CNS) toxicity of hyperfractionated total body irradiation (TBI). Int J Radiat Oncol Biol Phys. 12. 1. 2000;48(5):1497-501. X-1. [pmid: 11121654].
1823 Westbrook LE, Devinsky O, Geocadin R. Nonepileptic seizures after head injury. Epilepsia. 09. 1998;39(9):978-82. X-1, X-5. [pmid: 9738677].
1824 Wetzel CD, Squire LR. Encoding in anterograde amnesia. Neuropsychologia. 1980;18(2):177-84. X-1. [pmid: 7383309].
1825 Wetzel CD, Squire LR. Cued recall in anterograde amnesia. Brain Lang. 01. 1982;15(1):70-81. X-1. [pmid: 7059792].
1826 Wheeler BL, Shiflett SC, Nayak S. Effects of number of sessions and group or individual music therapy on the mood and behavior of people who have had strokes or traumatic brain injuries. Nordic Journal of Music Therapy. 2003;12(2):139-51. X-1, X-5.
1827 Whitaker AH, Van Rossem R, Feldman JF, et al. Psychiatric outcomes in low-birthweight children at age 6 years: relation to neonatal cranial ultrasound abnormalities. Arch Gen Psychiatry. 09. 1997;54(9):847-56. X-1, X-3, X-5. [pmid: 9294376].
1828 Whitlock FA. The aetiology of hysteria. Acta Psychiatr Scand. 1967;43(2):144-62. X-1. [pmid: 6077782].
1829 Whitlock FA. The Ganser syndrome. Br J Psychiatry. 01. 1967;113(494):19-29. X-1, X-5. [pmid: 6029366].
1830 Whitlock FA. The neurology of affective disorder and suicide. Aust N Z J Psychiatry. 03. 1982;16(1):1-12. X-1, X-2, X-4, X-5. [pmid: 6956326].
1831 Whitmyer VG, Dunner DL, Kornstein SG, et al. A comparison of initial duloxetine dosing strategies in patients with major depressive disorder. Journal of Clinical Psychiatry. 2007;68(12):1921-1930. X-1. [pmid: 18162024].
1832 Whitnall L, McMillan TM, Murray GD, et al. Disability in young people and adults after head injury: 5–7 year follow up of a prospective cohort study. J Neurol Neurosurg Psychiatry. 05. 2006;77(5):640-5. X-1. [pmid: 16614025].
1833 Whitney FW, Burns EM, Frederic M, et al. Depression in stroke survivors: the relationship of laterality in right and left hemisphere damage. Rehabilitation Nursing Research. 1994;3(4):130-40. X-1.
1834 Whittaker R, Kemp S, House A. Illness perceptions and outcome in mild head injury: a longitudinal study. J Neurol Neurosurg Psychiatry. 06. 2007;78(6):644-6. X-1. [pmid: 17507448].
1835 Wicklund AH, Ammar A, Weitlauf JC, et al. MMPI-2 patterns in electrical injury: a controlled investigation. Clin Neuropsychol. 01. 2008;22(1):98-111. X-1, X-5. [pmid: 18247220].
1836 Wilcox JA, Nasrallah HA. Childhood head trauma and psychosis. Psychiatry Res. 08. 1987;21(4):303-6. X-3. [pmid: 3628613].
1837 Wildberger H, Hofmann H, Siegfried J. Fluctuations of visual evoked potential amplitudes and of contrast sensitivity in Uhthoff’s symptom. Doc Ophthalmol. 03. 1987;65(3):357-65. X-1, X-5. [pmid: 3678007].
1838 Willer BS, Allen KM, Liss M, et al. Problems and coping strategies of individuals with traumatic brain injury and their spouses. Arch Phys Med Rehabil. 06. 1991;72(7):460-4. X-5. [pmid: 2059116].
1839 Williams KR, Galas J, Light D, et al. Head injury and alexithymia: implications for family practice care. Brain Inj. 04. 2001;15(4):349-56. X-1. [pmid: 11299135].
1840 Williams MGH. A population-based assessment of family caregivers of children with brain injury. Rush University. 2001:166. X-1, X-2, X-3, X-5.
1841 Williams SE, Bell DS, Gye RS. Neurosurgical disease encountered in a psychiatric service. J Neurol Neurosurg Psychiatry. 01. 1974;37(1):112-6. X-1, X-5. [pmid: 4813424].
1842 Williams WH, Evans JJ, Wilson BA. Neurorehabilitation for two cases of posttraumatic stress disorder following traumatic brain injury. Cogn Neuropsychiatry. 02. 2003;8(1):1-18. X-1, X-5. [pmid: 16571547].
1843 Wilson JT, Pettigrew LE, Teasdale GM. Emotional and cognitive consequences of head injury in relation to the glasgow outcome scale. J Neurol Neurosurg Psychiatry. 08. 2000;69(2):204-9. X-1, X-4. [pmid: 10896694].
1844 Wing YK, Lee S, Chiu HFK, et al. A patient with coexisting narcolepsy and morbid jealousy showing favourable response to fluoxetine. Postgraduate Medical Journal. 1994;70(819):34-36. X-1, X-5. [pmid: 8140016].
1845 Winhusen T, Somoza E, Ciraulo DA, et al. A double-blind, placebo-controlled trial of tiagabine for the treatment of cocaine dependence. Drug & Alcohol Dependence. 2007;91(2–3):141-148. X-1, X-5. [pmid: 17629631].
1846 Wirbel RJ, Olinger A, Karst M, et al. Treatment of severe injuries caused by attempted suicide: pattern of injury and influence of the psychiatric disorder on the postoperative course. Eur J Surg. 02. 1998;164(2):109-13. X-1, X-5. [pmid: 9537717].
1847 Witol AD, Webbe FM. Soccer heading frequency predicts neuropsychological deficits. Arch Clin Neuropsychol. 05. 2003;18(4):397-417. X-1. [pmid: 14591454].
1848 Won Kim S, Pio Hong J, Kee Min W, et al. Accurate, firm stabilization using external pins: a proposal for closed reduction of unfavorable nasal bone fractures and their simple classification. Plast Reconstr Surg. 10. 2002;110(5):1240-6. discussion 1247–8. X-1, X-5. [pmid: 12360061].
1849 Wong EC, Marshall GN, Shetty V, et al. Survivors of violence-related facial injury: psychiatric needs and barriers to mental health care. Gen Hosp Psychiatry. 03–04. 2007;29(2):117-22. X-1, X-5. [pmid: 17336660].
1850 Woo MA, Kumar R, Macey PM, et al. Brain injury in autonomic, emotional, and cognitive regulatory areas in patients with heart failure. J Card Fail. 04. 2009;15(3):214-23. X-1. [pmid: 19327623].
1851 Wood MM, Reilly PL, David DJ. Neuropsychologic outcome after craniofacial fracture. J Craniofac Surg. 10. 1990;1(4):163-6. X-5. [pmid: 2098174].
1852 Wood RA. Memory loss. Br Med J (Clin Res Ed). 05. 12. 1984;288(6428):1443-7. X-1.
1853 Wood RL, Liossi C, Wood L. The impact of head injury neurobehavioural sequelae on personal relationships: preliminary findings. Brain Inj. 09. 2005;19(10):845-51. X-1, X-2, X-5. [pmid: 16175844].
1854 Wood RL, McCrea JD, Wood LM, et al. Clinical and cost effectiveness of post-acute neurobehavioural rehabilitation. Brain Inj. 02. 1999;13(2):69-88. X-1. [pmid: 10079953].
1855 Wood RL, Rutterford NA. Demographic and cognitive predictors of long-term psychosocial outcome following traumatic brain injury. J Int Neuropsychol Soc. 05. 2006;12(3):350-8. X-1. [pmid: 16903127].
1856 Wood RL, Rutterford NA. The impact of mild developmental learning difficulties on neuropsychological recovery from head trauma. Brain Inj. 05. 2006;20(5):477-84. X-1. [pmid: 16716994].
1857 Wood RL, Rutterford NA. Psychosocial adjustment 17 years after severe brain injury. J Neurol Neurosurg Psychiatry. 01. 2006;77(1):71-3. X-1. [pmid: 16361596].
1858 Wood RL, Williams C. Neuropsychological correlates of organic alexithymia. J Int Neuropsychol Soc. 05. 2007;13(3):471-9. X-1. [pmid: 17445296].
1859 Wood RL, Williams C. Inability to empathize following traumatic brain injury. J Int Neuropsychol Soc. 03. 2008;14(2):289-96. X-1. [pmid: 18282326].
1860 Wood RLL, Williams C, Kalyani T. The impact of alexithymia on somatization after traumatic brain injury. Brain Injury. 07. 2009;23(7–8):649-654. X-1. [pmid: 19557568].
1861 Woolley EJ, Jones DC. The use of the image intensifier in fractures of the zygomatic arch--a technical note. Int J Oral Maxillofac Surg. 06. 2005;34(4):440-2. X-1, X-2, X-5. [pmid: 16053857].
1862 Woo-Sam J, Zimmerman IL, Brink JD, et al. Socio-economic status and post-trauma intelligence in children with severe head injuries. Psychol Rep. 08. 1970;27(1):147-53. X-1. [pmid: 5454092].
1863 Worster-Drought C. Speech disorders in children. Dev Med Child Neurol. 08. 1968;10(4):427-40. X-1. [pmid: 5681554].
1864 Wright MT, Cummings JL, Mendez MF, et al. Bipolar syndromes following brain trauma. Neurocase. 1997;3(2):111-118. X-1, X-5.
1865 Wrobel BB, Leopold DA. Smell and taste disorders. Facial Plastic Surgery Clinics of North America. 2004;12(4):459-468. X-1, X-2, X-5. [pmid: 15337114].
1866 Wroblewski BA, Guidos A, Leary JM, et al. Control of depression with fluoxetine and antiseizure medication in a brain-injured patient. American Journal of Psychiatry. 02. 1992;149(2):273. X-5. [pmid: 1734754].
1867 Wroblewski BA, Joseph AB, Cornblatt RR. Antidepressant pharmacotherapy and the treatment of depression in patients with severe traumatic brain injury: a controlled, prospective study. J Clin Psychiatry. 12. 1996;57(12):582-7. X-5. [pmid: 9010122].
1868 Wylen EL, Willis BK, Nanda A. Infection rate with replacement of bone fragment in compound depressed skull fractures. Surg Neurol. 04. 1999;51(4):452-7. X-1. [pmid: 10199302].
1869 Yamaguchi M. Incidence of headache and severity of head injury. Headache. 10. 1992;32(9):427-31. X-1. [pmid: 1446984].
1870 Yamasato M, Satoh S, Ikejima C, et al. Reliability and validity of questionnaire for neurobehavioral disability following traumatic brain injury. Psychiatry Clin Neurosci. 12. 2007;61(6):658-64. X-1, X-4, X-5. [pmid: 18081628].
1871 Yanagawa Y, Kaneko N, Higashidate S, et al. Accidental fall due to abnormal behavior after experiencing a Streptococcus pyogenes infection: Febrile delirium or pediatric autoimmune neuropsychiatric disorder associated with streptococcal infection. Pediatric Emergency Care. 2009;25(8):523-524. X-1, X-5. [pmid: 19687712].
1872 Yang CC, Tu YK, Hua MS, et al. The association between the postconcussion symptoms and clinical outcomes for patients with mild traumatic brain injury. J Trauma. 03. 2007;62(3):657-63. X-6. [pmid: 17414343].
1873 Yang L, Benardo LS. Valproate prevents epileptiform activity after trauma in an in vitro model in neocortical slices. Epilepsia. 12. 2000;41(12):1507-13. X-1, X-3. [pmid: 11114207].
1874 Yang Z, Yan K, Williams S, et al. An unusual cause of abdominal pain in a patient with severe traumatic brain injury (TBI): Intussusception of the jejunum. American Journal of Physical Medicine and Rehabilitation. 2009;88(10):864-865. X-1, X-5. [pmid: 19661775].
1875 Yaremchuk MJ, Kim WK. Soft-tissue alterations associated with acute, extended open reduction and internal fixation or orbital fractures. J Craniofac Surg. 11. 1992;3(3):134-40. X-1, X-5. [pmid: 1298411].
1876 Yassa R, Cvejic J. Valproate in the treatment of posttraumatic bipolar disorder in a psychogeriatric patient. Journal of Geriatric Psychiatry and Neurology. 01–03. 1994;7(1):55-57. X-1, X-5. [pmid: 8192831].
1877 Yasseen B, Colantonio A, Ratcliff G. Prescription medication use in persons many years following traumatic brain injury. Brain Inj. 09. 2008;22(10):752-7. X-1. [pmid: 18787984].
1878 Yavuz MS, Asirdizer M, Cetin G, et al. The correlation between skull fractures and intracranial lesions due to traffic accidents. Am J Forensic Med Pathol. 12. 2003;24(4):339-45. X-1. [pmid: 14634472].
1879 Yeh J, Kim H, Nates L. Case of the month: case 1/2001 shooting nails in his head. Internet Journal of Emergency & Intensive Care Medicine. 2001;5(1). X-5.
1880 Yeh PJ, Kim DH, Nates JL. Case of the month: case 1/2001. Internet Journal of Advanced Nursing Practice. 2000;4(2). X-5.
1881 Young AB, Ott LG, Beard D, et al. The acute-phase response of the brain-injured patient. J Neurosurg. 09. 1988;69(3):375-80. X-1, X-5. [pmid: 3136234].
1882 Young RS, Gillan E, Dingmann P, et al. Army health care operations in Iraq. Conn Med. 01. 2008;72(1):13-7. X-1, X-2, X-4, X-5. [pmid: 18286877].
1883 Yuksel F, Celikoz B, Ergun O, et al. Management of maxillofacial problems in selfinflicted rifle wounds. Ann Plast Surg. 08. 2004;53(2):111-7. X-1, X-5. [pmid: 15269577].
1884 Yuluğ B, Ozan E, Gönül AS, et al. Brain-derived neurotrophic factor, stress and depression: A minireview. Brain Research Bulletin. 03. 2009;78(6):267-269. X-1, X-2. [pmid: 19111910].
1885 Yunus MB. Fibromyalgia and Overlapping Disorders: The Unifying Concept of Central Sensitivity Syndromes. Seminars in Arthritis & Rheumatism. 2007;36(6):339-356. X-1, X-2, X-5. [pmid: 17350675].
1886 Zahn BS, Littman SI. Depression in survivors of severe traumatic brain injury: Issues in assessment and management. Psychiatric Forum. Win. 1989;15(1):6-10. X-2.
1887 Zalihic A, Zalihic D, Pivic G. Influence of posttraumatic stress disorder of the fathers on other family members. Bosn J Basic Med Sci. 02. 2008;8(1):20-6. X-1, X-2, X-5. [pmid: 18318667].
1888 Zazzali JL, Marshall GN, Shetty V, et al. Provider perceptions of patient psychosocial needs after orofacial injury. J Oral Maxillofac Surg. 08. 2007;65(8):1584-9. X-1, X-5. [pmid: 17656287].
1889 Zbinden B, Kaiser G. Specific aspects of depressed skull fractures in childhood. Z Kinderchir. 02. 1989;44(1):3-7. X-1, X-3, X-5. [pmid: 2497600].
1890 Zedkova L, Coupland NJ. Adverse reactions associated with fluvoxamine. J Psychiatry Neurosci. 09. 1998;23(4):242-3. X-5. [pmid: 9785705].
1891 Zedkova L, Coupland NJ. Adverse reactions associated with fluvoxamine [letter]. Journal of Psychiatry and Neuroscience. 09. 1998;23(4):242-243. X-5. [pmid: 9785705].
1892 Zeitzer JM, Friedman L, O’Hara R. Insomnia in the context of traumatic brain injury. Journal of Rehabilitation Research and Development. 2009;46(6):827-835. X-1, X-2. [pmid: 20104406].
1893 Zhang HY, Tang XC. Studies of natural products on treating neurological disorders in China. Cellular & Molecular Neurobiology. 2008;28(1):9-12. X-1, X-2. [pmid: 18041577].
1894 Zhang QB, Dong YJ, Li ZB, et al. Coronal incision for treating zygomatic complex fractures. J Craniomaxillofac Surg. 04. 2006;34(3):182-5. X-1, X-5. [pmid: 16533601].
1895 Zhang S, Carroll LJ, Cassidy JD, et al. Factors influencing self-rated health in trafficrelated mild traumatic brain injury. J Rehabil Med. 11. 2009;41(13):1062-7. X-1. [pmid: 19894002].
1896 Ziegler MG, Morrissey EC, Marshall LF. Catecholamine and thyroid hormones in traumatic injury. Crit Care Med. 03. 1990;18(3):253-8. X-1, X-5. [pmid: 2302947].
1897 Ziino C, Ponsford J. Measurement and prediction of subjective fatigue following traumatic brain injury. J Int Neuropsychol Soc. 07. 2005;11(4):416-25. X-1. [pmid: 16209422].
1898 Zimmer B, Kant R, Zeiler D, et al. Antidepressant efficacy and cardiovascular safety of venlafaxine in young vs old patients with comorbid medical disorders. International Journal of Psychiatry in Medicine. 1997;27(4):353-364. X-1, X-5. [pmid: 9565731].
1899 Zucker DK, Austin FM, Branchey L. Variables associated with alcoholic blackouts in men. Am J Drug Alcohol Abuse. 1985;11(3–4):295-302. X-1, X-5. [pmid: 4091163].
1900 Zun L, Gold I. A survey of the form of the mental status examination administered by emergency physicians. Ann Emerg Med. 08. 1986;15(8):916-22. X-1. [pmid: 3740577].