# Evidence Tables

Evidence Table 1 TBI and Depression

Study Description | Inclusion/Exclusion Criteria | Population and Baseline Characteristics | Study Definitions | Depression Incidence/Prevalence & Co-morbidities
Author: Al-Adawi et al., 2007 Country, Setting: Oman, tertiary care center Enrollment Period: NR Design: Cross-sectional Time from injury, months± SD: 18.2 ± 12.2 Length of follow up: NA Dep. Scale/Tool: HADS, CIDI | Inclusion criteria:; - A score of 51 or higher on the 17- item Awareness Questionnaire; Exclusion criteria:; - Pre-injury psychiatric or neurological history other than TBI; - Non-Omani; - Sensory or cognitive impairments that would preclude completion of the protracted assessment; TBI Def: An injury to brain tissues caused by an external mechanical force as evidenced by LOC, post-traumatic cognitive and behavioral changes or objective neurological finding Mild TBI: GCS score of 13 to 15 Moderate TBI: GCS score of 9 to 12 Severe TBI: GCS score of 3 to 8 | Group(s): Patients with TBI N screened: NR N eligible: NR N included: 68 N at conclusion: NA Depression: Prior to injury: None (see exclusion criteria) At time of injury: None (see exclusion criteria) Other preexisting psychiatric conditions: None (see exclusion criteria) N with prior TBI: NR Age, yrs ± SD:^*^ 31.1 ± 7.6 Age ≥16, n (%): 68 (100) Global injury severity: NR Severity of TBI: Mild or moderate: majority of patients (exact number NR) Mechanism/type of injury: NR Area of brain injured, n (%): Diffuse: 21 (32.6) Focal: 14 (20.6) Frontal: 25 (36.8) | Depression: HADS: score ≥8 indicated propensity for depression/ anxiety CIDI: clinical depression/ anxiety determined by clinical interview Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, HADS, n (%): 13 (19.1) Depression, CIDI, n (%): 39 (57.4) Taking depression medications (%): NR Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR
Author: Aloia et al., 1995 Country, Setting: US, other Enrollment Period: NR Design: Cross-sectional Time from injury: NR Length of follow up: NA Dep. Scale/Tool: MMPI | Inclusion criteria:; - Sample of private practice patients based on group criteria; Exclusion criteria: See inclusion criteria TBI Def: NR | Group(s): G1: HI and depression G2: HI and no depression G3: No HI and depression G4: No HI and no depression N screened: NR N eligible: NR N included: G1: 277 G2: 471 G3: 220 G4: 214 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, mean yrs: G1: 35.2 G2: 31.5 G3: 38.5 G4: 38.3 Age ≥16: NR Global injury severity: NR Severity of TBI: NR | Depression: MMPI: T score of 70 or higher on the depression (D) scale Discriminate Functional analysis (DFA) and cross validation used to determine if characteristics of depression were the same for HI and no HI groups Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, MMPI, n: 497 (42.0) MMPI depression (D) scale score, mean: G1: 84.6 G2: 55.9 G3: 86.7 G4: 56.4 Discriminate Functional analysis (DFA): Analysis for depression using entire HI population was successful (85.8%), cross validation with no HI group successful as well (85.6%, Õ^2^ = 0.0, P > 0.10) Analysis for no HI group was successful (92.4%) and cross validation was equally successful (77.4%, Õ^2^ = 2.4, P > 0.10) When MMPI variables removed, DFA not as successful in classifying HI patients as depressed or not depressed, cross validation only successful (48.3%, Õ^2^ =13.2, P > 0.001) May imply that neuropsychological variables associated with depression are not the same in HI vs. no HI patients
Author: Ashman et al., 2009 Country, Setting: US, tertiary care hospital Enrollment Period: NR Design: Prospective cohort Time from injury, yrs ± SD: G1: 18.6 ± 13.8 G2: 16.6 ± 13.9 Length of follow up: 10 weeks Dep. Scale/Tool: SCID, HAM-D | Inclusion criteria:; - At least 18 yrs old; - A history of TBI with a documented LOC or other evidence of a TBI (e.g., pathology on neuroimaging); - At least 6 mos postinjury; - Meet DSM-IV diagnostic criteria for MDE; - HAM-D score ≥ 18; - Able to comprehend or answer verbal or written questionnaires; Exclusion criteria:; - Using antidepressant medication; - Currently in psychotherapy; - Active suicidal plans or depression severe enough to require hospitalization; - Serious medical illness; - Pregnant or breast-feeding; - Mass brain lesions or other neurologic diagnoses other than TBI; - A history of current or past psychosis or mania using DSM- IV criteria | Group(s): G1: Sertraline group G2: Placebo group N screened: 91 N eligible: 52 N included: G1: 22 G2: 19 N at conclusion: G1: 22 G2: 19 Depression: Prior to injury: See inclusion criteria At time of injury: See inclusion criteria Other preexisting psychiatric conditions: See inclusion criteria N with prior TBI: NR Age, yrs ± SD: G1: 46.8 ± 12.8 G2: 51.5 ± 8.2 Age ≥16, n (%): 52 (100) Global injury severity: NR Severity of TBI, %: Mild: G1: 20.0 G2: 50.0 Moderate: G1: 46.6 G2: 31.3 Severe: G1: 33.4 G2: 18.8 | Depression: SCID: DSM-IV criteria HAM-D ≥ 18 Other co- morbidities: PTSD: NR Other anxiety disorder: Beck Anxiety Inventory Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Life-3 | Depression, SCID, n (%): G1: 4 (18) G2: 7 (37) HAM-D score, mean ± SD: Baseline: G1: 27.5 ± 7.1 G2: 25.2 ± 8.0 End of treatment: G1: 13.7 ± 9.7 G2: 16.2 ± 9.6 Taking depression medications: None (see exclusion criteria) Other co- morbidities: PTSD: NR Other anxiety disorder: BAI score, mean ± SD: Baseline G1: 23.2 ± 15.2 G2: 20.5 ± 14.9 End of treatment: G1: 11.1 ± 11.9 G2: 13.1 ± 11.6 Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Life-3 score, mean ± SD: G1: 6.3 ± 8.0 G2: 4.9 ± 3.5
Author: Ashman et al., 2004 See Hibbard et al., 2004 Country, Setting: US, tertiary care center Enrollment Period: March 1995 to December 2000 Design: Prospective cohort Time from injury: Initial assess-ment (T1) 3 months to 4 years post injury Length of follow up (years): Second (T2) and third (T3) assessments 12 and 24 months after initial assessment Dep. Scale/Tool: SCID | Inclusion criteria:; - Self-identified TBI; - 3 months to 4 years postinjury; - Between age 18 and 87; - Residents of the United States living within the community; - Capable of giving informed consent for participation and answering interviews independently; Exclusion criteria:; - The presence of an acquired brain injury (e.g., cerebrovascular accident, aneurysm); - A preexisting neurocognitive disorder; - Any preexisting psychotic disorder (e.g., schizophrenia, psychoses NOS, depression with psychotic features); TBI Def: According to ACRM criteria | Group(s): Patients with TBI N screened: NR N eligible: NR N included: 188 N at conclusion: 83 Depression, %: Prior to injury: 20 At time of injury: NR Other preexisting psychiatric conditions, %: PTSD: 10 Anxiety disorder: 16 Substance use: 32 Other psychiatric conditions: 5 N with prior TBI: NR Age, yrs ± SD: 40.4 ± 15.1 Age ≥16, n (%): 188 (100) Global injury severity: NR Severity of TBI, %: Moderate to severe: 62 Mild : 29 LOC of unknown duration: 9 Mechanism/type of injury: NR Area of brain injured: NR Concomitant injuries: NR | Depression: SCID: DSM-IV criteria Other co- morbidities: PTSD: SCID Other anxiety disorder: SCID: OCD, GAD, panic, phobias Irritability: NR Aggression: NR Suicidality: NR Substance use: SCID: abuse and dependence Other psychiatric conditions: SCID: any axis I disorder other than above Health related QoL or functional status: NR | Depression, %: Initial assessment: 35 12 months: 24 24 months: 21 Taking depression medications: NR Other co- morbidities, %: PTSD: Initial assessment: 30 12 months: 18 24 months: 21 Other anxiety disorder: Initial assessment: 27 12 months: 19 24 months: 9 Irritability: NR Aggression: NR Suicidality: NR Substance use: Initial assessment: 14 12 months: 10 24 months: 17 Other psychiatric conditions: Initial assessment: 9 12 months: 5 24 months: 0 Health related QoL or functional status: NR
Author: Bay and Donders, 2008 See Bay et al. 2002 & Bay et al. 2007 Country, Setting: US, rehabilitation center Enrollment Period: NR Design: Cross-sectional Time from injury, mos ± SD (range): 15.1 ± 11.3 (1–36) Length of follow up: NA Dep. Scale/Tool: NFI-D | Inclusion criteria:; - 1 to 36 mos postinjury; - Must have been hospitalized (ED or in-patient for the injury); - Must be English speaking and competent to sign informed consent as determined by the admitting neuropsychologist; Exclusion criteria:; - History of neurological conditions known to affect cognition, such as Parkinson’s or Alzheimer’s disease; - Severe TBI according to admitting ED (GCS ≥9); TBI Def: NR^*^ | Group(s): G1: Borderline or clinically depressed patients with TBI G2: Not or minimally depressed patients with TBI N screened: NR N eligible: NR N included: G1: 49 G2: 35 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions, n (%): “Prior psychiatric history”: 26 (31.0) Prior history of substance abuse, n (%): 14 (16.7) N with prior TBI: NR Age, yrs ± SD: 38.0 ± 11.3 Age ≥16: NR Global injury severity: NR Severity of TBI, GCS, n (%): 13–15: 65 (77.4) 9–12: 19 (22.6) | Depression: NFI-D: 13–28: Minimally depressed 29–42: Borderline depressed 43–65: Clinically depressed Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: PSS IES-R MPQ-SF MFIS: 0: None 1: Mild 2: Moderate 3: Severe Reaction time: index of information processing speed | Depression, n (%): Total: 49 (58.3) NFI-D score, mean ± SD: G1: 39.6 ± 6.1 G2: 20.7 ± 4.4 Total: 31.7 (10.8) NFI-D score, median (range): Total: 32 (13–56) Taking depression medications (%): NR Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: PSS score, mean ± SD: G1: 27.4 ± 5.5 G2: 19.7 ± 4.3 IES-R score, mean ± SD: G1: 22.7 ± 8.8 G2: 12.1 ± 8.5 MPQ-SF score, mean ± SD: G1: 1.5 ± 1.0 G2: 0.6 ± 0.9
Author: Bay et al., 2002^ Bay et al., 2007 See Bay and Donders, 2008 Country, Setting: US, rehabilitation centers Enrollment Period: NR Design: Cross-sectional Time from injury, mos ± SD: 9.57 ± 6.31 Length of follow up: NA Dep. Scale/Tool: NFI-D, POMS-D, CES-D | Inclusion criteria:; - 18 to 65 years old; - Mild or moderate brain injury; - Hospitalization for the injury; - Evaluation by a neuropsychologist with expertise in assessment of brain injury; - Within two years of the injury; - English-speaking; - Not psychotic at the time of neuropsychologic al evaluation; - No preinjury neurological impairment; - A relative or significant other (R/SO) who agreed to participate; Exclusion criteria:; - Severe TBI; TBI Def: Mild TBI: According to ACRM criteria Moderate TBI: LOC exceeding 30 minutes but less than 2 weeks, GCS score of 9–12 or 13–15 with an abnormal CT scan^ | Group(s): Patients with mild or moderate TBI N screened: NR N eligible: NR N included: 75 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions, n (%): Psychiatric disorders including depression: 15 (20) Suicidal thoughts in the year prior to injury: 6 (8) N with prior TBI, n (%): 12 (16.0) Age, yrs ± SD: 37.4 ± 12.1 Age ≥16, n (%): 75 (100) Global injury severity: NR Severity of TBI, %: Mild: 50 Moderate: 50 PTA duration, mean days ± SD: 7.7 ± 8.9 | Depression: NFI-D: 13–28: Minimally depressed 29–42: Borderline depressed 43–65: Clinically depressed POMS-D: NR CES-D: 16–20: Mild depression 21–26: Moderate 27–60: Severe Other co- morbidities: PTSD:NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, NFI-D, n (%): Clinical: 11 (14.7) Borderline: 30 (40.0) Minimal: 34 (45.3) NFI-D score, mean ± SD (range): 30.7 ± 10.7 (13–54) POMS-D score, mean ± SD (range): 15.0 ± 14.1 (0–59) Depression, CES-D, n: Probable MDD: 22 (29.4) Moderate: 16 (21.3) Mild: 10 (13.3) Not in depression range: 27 (36)^ CES-D > 30.5: 12 (20)^ CES-D score, mean ± SD (range): 20.5 ± 13.2 (0–57) Taking depression medications (%): 40 Other co- morbidities: PTSD:NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR
Author: Bombardier et al., 2006 See Fann et al., 2005; Fann et al., 2009: Bombardier et al., 2010 Country, Setting: US, trauma center Enrollment Period: May 2001 to January 2003 Design: Prospective cohort Time from injury: Up to 6 months Length of follow up, mos: 6 Dep. Scale/Tool: PHQ-9 | Inclusion criteria:; - At least 18 yrs old; - English speaking; - Residing in King, Pierce, Kitsap, or Snohomish counties (WA); Exclusion criteria:; - Uncomplicated MTBI; - Homelessness,; - Incarceration; - A history of schizophrenia; - Participation in an investigational drug study; TBI Def: Radiological evidence of acute brain abnormality or lowest GCS score less than or equal to 12 within the first 24 hours since admission. Complicated mild TBI: GCS of > 12 and abnormal CT Uncomplicated MTBI: GCS of 13 to 15 and no CT abnormality Moderate TBI: GCS of 9 to 12 Severe TBI: GCS of ≤ 8 | Group(s): Patients with TBI G1: Patients with TBI and PTSD G2: Patients with TBI and no PTSD N screened: NR N eligible: 211 N included: 141 N at conclusion: G1: 14 G2: 110 Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions, n (%): History of anxiety or depression: 68 (54.8) N with prior TBI: NR Age, yrs ± SD: 43 ± 18.6 Age ≥16, %: 100 Global injury severity: NR Severity of TBI, %: Comp. Mild: 44 Moderate: 30 Severe: 27 Mechanism/type of injury, %: MVC: 49 Falls: 32 Assault: 7 Other: 12 | Depression: PHQ-9: NR Other co- morbidities: PTSD: PCL-C Criteria F Other anxiety disorder: PHQ Self-history Irritability: NR Aggression: NR Suicidality: NR Substance use: Positive for Toxicology screening test for amphetamines/ Cocaine Other psychiatric diagnoses: NR Health related QoL or functional status: Cognistat GHS of SF-36 | Depression, PHQ- 9, n (%): MDD: 27 (21.8)^ MDD, %: G1: 71.4 G2: 15.5 P < 0.001 Taking depression medications: NR Other co- morbidities, n (%): PTSD: 14 (11.3) PTSD + criteria F: 10 (8^*^) PTSD + all criteria (A2,B,C,D,F,PCL-C): 7/125 (5.6^*^) Other anxiety disorder: PHQ, %: G1: 21.4 G2: 4.5 P < 0.046 Other anxiety disorders, %: G1: 71.4 G2: 18.2 P < 0.001 Irritability: NR Aggression: NR Suicidality: NR Substance use: Positive toxicology test for amphetamine/Cocaine, n (%): G1: 4 (3.2) G2: 8 (7.3) Other psychiatric diagnoses: NR
Author: Bombardier et al., 2010 See Fann et al., 2005; Bombardier et al., 2006; Fann et al., 2009 Country, Setting: US, trauma center Enrollment Period: June 2001 to March 2005 Design: Prospective cohort Time from injury, mos, n: 1: 289 2: 380 3: 408 4: 415 5: 423 6: 432 8: 385 10: 358 12: 365 Length of follow up: 12 mos Dep. Scale/Tool: Structured interview based on PHQ-9 | Inclusion criteria:; - At least 18 yrs old; - English speaking; - Admission to Harborview Medical Center (a level I trauma center in Seattle, Washington); - TBI and radiological evidence of acute, traumatically induced brain abnormality or GCS score lower than 13 (based on the lowest score within 24 hours after admission or the first after paralytic agents were withdrawn); Exclusion criteria:; - Uncomplicated mild TBI (GCS 13–15 and no radiological abnormality); - Homelessness (or no contact information available); - Incarceration; - Schizophrenia | Group(s): G1: Participants with MDD G2: Participants without MDD N screened: NR N eligible: 1,080 N included^*^: 559 G1: 262 G2: 297 N at conclusion: 365 Depression, n (%): Prior to injury: 150 (26.7) At time of injury: 88 (15.7) Other preexisting psychiatric conditions, n (%): Unspecified diagnosis: 61 (10.9) PTSD: 36 (6.4) N with prior TBI (%): NR Age, yrs ± SD: 42.5 ± 17.9 Age ≥16, N (%): 559 (100) Global injury severity^†^, n (%): 0:153 (27.4) 1–2: 192 (34.4) 3–5: 212 (37.9) | Depression: PHQ-9: MDD based on DSM-IV criteria Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: CAGE Other psychiatric diagnoses: NR Health related QoL or functional status: SF-36 EQoL | Depression, n (%): 1 mo: 90/289 (31.1) 2 mos: 94/380 (24.7) 3 mos: 100/408 (24.5) 4 mos: 91/415 (21.9) 5 mos: 97/423 (22.9) 6 mos: 90/432 (20.8) 8 mos: 93/385 (24.2) 10 mos: 97/358 (27.1) 12 mos: 85/365 (23.3) Any time: 297 (53.1) ≥1 positive screening, %: 27.0 Positive screening in ≥6 mos, %: 36.0 Taking depression medications (%): G1: 41.0 G2: 18.0 RR=2.3 95% CI (1.7,3.1) Other co- morbidities: PTSD: NR Other anxiety disorder: G1: 54.0 G2: 6.0 RR= 8.8 95% CI (5.4, 14.4) Irritability: NR Aggression: NR Suicidality: NR Substance use: NR
Author: Brooks et al., 1987 Country, Setting: UK, rehabilitation center Enrollment Period: NR Design: Cross-sectional Time from injury, mean yrs (range): 3.4 (2–8) Length of follow up: NA Dep. Scale/Tool: Questionnaire by structured interview of patients and relatives | Inclusion criteria:; - Coma duration of at least 6 hrs; - Intracranial hematoma requiring surgery; - PTA of at least two days; Exclusion criteria: See inclusion criteria TBI Def: NR | Group(s): Patients with severe closed- head injury N screened: NR N eligible: NR N included: 134 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, time of assessment, n (%): 15–25: 34 (25.4) 26–35: 25 (18.7) 36–45: 23 (17.2) 46–55: 23 (17.2) 56–65: 21 (15.7) 65–70: 7 (5.2) Missing: 1 (0.7) Age ≥16: NR Global injury severity: NR Severity of TBI, PTA, n (%): 2–14 days: 34 (25.4) 15–28 days: 31 (23.1) 1–2 months: 32 (23.9) 3–6 months 23 (17.2) >6 months: 3 (2.2) Missing: 11 (8.2) | Depression: Internally developed structured questionnaires administered to patient and to close family member, querying depression Other co- morbidities: PTSD: NR Other anxiety disorder: Internally developed structured questionnaire administered to patient and to close family member, querying tension/anxiety/ worry Irritability: See Aggression Aggression: Internally developed structured questionnaire administered to patient and to close family member, querying anger/ irritation/impatience Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR | Depression, %: Patient report: 49 Relative report: 63 Taking depression medications: NR Other co- morbidities, %: PTSD: NR Other anxiety disorder: Patient report: 35 Relative report: 65 Irritability: See Aggression Aggression: Patient report: 62 Relative report: 74 Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status, reported by relative, %: Worrying that patient could not be left in charge of the household: 47 Patient still needed “looking after”: 36 Relative worried about patient going out alone: 24 Washing difficulty: 20 Problems with personal hygiene: 27
Author: Brown et al., 2004 Country, Setting: US, trauma center Enrollment Period: August 1999 to March 2001 Design: Cross-sectional Time from injury, wks ± SD: 12 ± 2 Length of follow up: NA Dep. Scale/Tool: SCID, CES-D, VAS-D | Inclusion criteria:; - Age 16 or older; - Residence within Harris County, TX; Exclusion criteria:; - Penetrating missile injury of the brain; - History of diagnosed schizophrenia; - Mental deficiency; - Hospitalization for prior TBI; - History of treatment for recent substance abuse; - Blood alcohol level > 200 mg/dL when examined in ER; TBI Def: Mild TBI: A closed head injury producing a LOC ≤ 20 min, lowest postresuscitation GCS of 13 to 15, no extracranial injury that necessitated surgical repair under general anesthesia, and CT findings after 24 hours indicating normal intracranial findings or a brain lesion that did not require surgical evacuation Moderate TBI: Lowest post- resuscitation GCS of 9 to 12 with or without evidence of lesion on CT | Group(s): G1: Patients with TBI G2: Patients with general trauma (GT) Ga: European American patients Gb: Hispanic American patients Gc: African American patients N screened: G1: 399 G2: 255 N eligible: G1: 399 G2: 255 N included: G1: 135 G1a: 28 G1b: 63 G1c: 44 G2: 83 G2a: 17 G2b: 46 G2c: 20 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: G1: 33.9 ± 14.5 G2: 34.9 ± 12.7 Age ≥16, n (%): 218 (100) | Depression: SCID: DSM-IV criteria CES-D: NR VAS-D: NR Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: SF-36 (PCS/ MCS) CIQ SSQ | Depression, SCID, %: MDE: G1: 16 G1a: 11 G2b: 17 G1c: 18 CES-D score, mean ± SD: G1: 21.8 ± 14.8^*^ G1a: 17.9 ± 16.0 G1b: 21.3 ± 14.3 G1c: 24.9 ± 13.9 G2: 18.8 ± 14.6^*^ G2a: 17.5 ± 13.9 G2b: 18.9 ± 14.9 G2c: 19.7 ± 14.2 VAS-D score, mean ± SD: G1: 39.5 ± 34.8 G1a: 32.4 ± 35.7 G1b: 37.0 ± 32.8 G1c: 47.3 ± 36.5 G2: 26.7 ± 31.7 G2a: 21.2 ± 28.1 G2b: 30.1 ± 33.3 G2c: 23.5 ± 31.4 Taking depression medications: NR Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR
Author: Bryant et al., 2001 Country, Setting: Australia, rehabilitation center Enrollment Period: July 1994 to July 1997 Design: Cross-sectional Time from injury, mos ± SD: 6.4 ± 1.3 Length of follow up: NA Dep. Scale/Tool: BDI | Inclusion criteria:; - Admission to major brain injury rehabilitation center after severe TBI; Exclusion criteria:; - Insufficient cognitive ability to understand or respond to the interview; - Inability to speak English without an interpreter; TBI Def: NR | Group(s): G1: Patients with TBI and PTSD G2: Patients with TBI and no PTSD N screened: 161 N eligible: 96 N included: G1: 26 G2: 70 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: 34.26 ± 12.82 Age ≥16, n (%): 96 (100) Global injury severity (ISS, RTS, etc.): NR Severity of TBI, GCS score, mean ± SD: Total: 8.0 ± 3.8 G1: 6.9 ± 3.5 G2: 8.4 ± 3.8 Mechanism/type of injury, n: MVC: 70 Assault: 12 Work: 14 | Depression: BDI: > 30: Severe 25–29: Moderate 19–24: Mild 11–18: Minimal < 10: None Other co- morbidities: PTSD: PTSD-I Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: OAS, GHQ Health related QoL or functional status: FAM CIQ SWLS | Depression, %: Severe: 8 Moderate:11 Mild: 0 Minimal: 27 BDI score, mean ± SD: G1: 23.0 ± 13.9 G2: 9.9 ± 9.8 Taking depression medications (%): NR Other co- morbidities: PTSD, n (%): 26 (27) Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: OAS total score, mean ± SD: G1: 4.5 ± 3.8 G2: 2.5 ± 3.0 G1/G2: P = 0.01 GHQ score, mean ± SD: G1: 7.6 ± 3.4 G2: 3.5 ± 3.8 Health related QoL or functional status: FAM score, mean ± SD: G1: 198.8 ± 8.2 G2: 203.1 ± 6.8 G1/G2: P = 0.01
Author: Bryant et al., 2010 Country, Setting: Australia, trauma centers Enrollment Period: April 2004 to February 2006 Design: Prospective cohort Time from injury, mos : 3, 12 Length of follow up: 12 mos Dep. Scale/Tool: MINI | Inclusion criteria:; - 16 to 70 yrs old; - Hospital admission of more than 24 hours following traumatic injury; - Ability to understand and speak English proficiently; Exclusion criteria:; - Moderate or severe brain injury (LOC > 30 mins or GCS score < 13); - Currently psychotic or suicidal; - Non-Australian visitor; - Under police guard; TBI Def: Mild TBI: GCS score of 13–15; ICD-9 documented head injury, LOC<30 min, no focal neurologic deficit or intracranial complications | Group(s): G1: Participants with mild TBI randomly selected from trauma center admissions G2: Participants with no TBI randomly selected from trauma center admissions N screened: 1,477 N eligible: G1: 437 G2: 647 N included: G1: 377 G2: 555 N at conclusion: G1: 321 G2: 496 Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI (%): NR Age, yrs ± SD: 3 mos: 38.3 ± 13.6 12 mos: 38.9 ± 13.6 Age ≥16, N (%): 1,084 (100) | Depression: MINI: MDD Other co- morbidities: PTSD: Clinician Administered PTSD Scale-IV Other anxiety disorder: MINI Irritability: NR Aggression: NR Suicidality: NR Substance use: MINI Other psychiatric diagnoses: NR Health related QoL or functional status: WHOQOL | Depression, n (%): 3 mos: G1: 68 (18.0) G2: 93 (16.8) 12 mos: G1: 56 (17.5) G2: 77 (15.5) 54.7% depressed at 12 mos also depressed at 3 mos Taking depression medications: Receiving mental health treatment, %: 12 mos: 41.2 Other co- morbidities, n (%): PTSD: 3 mos: G1: 48 (12.7) G2: 42 (7.6) 12 mos: G1: 43 (13.0) G2: 36 (7.2) Other anxiety disorder: GAD: 3 mos: G1: 37 (9.8) G2: 47 (8.5) 12 mos: G1: 43 (13.4) G2: 48 (9.7) Other^*^ 3 mos: G1: 119 (31.6) G2: 112 (20.2) 12 mos: G1: 107 (33.3) G2: 105 (21.2) 59.9% with anxiety disorder at 12 mos also had disorder at 3 mos
Author: Chamelian and Feinstein, 2006 See Chamelian et al., 2004 Country, Setting: Canada, tertiary care hospital Enrollment Period: NR Design: Cross-sectional Time from injury: 6 months Length of follow up: NA Dep. Scale/Tool: SCID | Inclusion criteria:; - 18 to 60 yrs old; - Mild to moderate TBI; Exclusion criteria: See inclusion criteria TBI Def: Mild TBI: GCS score of 13 to 15, LOC < 20 minutes and PTA < 24 hours Moderate TBI: GCS score of 9 to 12, PTA > 24 hours but less than 1 week | Group(s): G1: Participants with subjective cognitive complaints G2: Participants without subjective cognitive complaints N screened: NR N eligible: NR N included: G1: 34 G2: 29 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions, n (%): G1: 17 (20.6) G2: 3 (10.3) N with prior TBI (%): G1: 7 (20.6) G2: 5 (17.2) Age, yrs ± SD: G1: 34.9 ± 12.8 G2: 31.3 ± 10.2 Age ≥16, n (%): 63 (100) Global injury severity: NR Severity of TBI, GCS score, mean ± SD: G1: 14.6 ± 0.7 G2: 13.7 ± 1.6 | Depression: SCID: DSM-IV criteria Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: CAGE Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, n (%): G1: 5 (18.5) G2: 0 Taking depression medications, %:^*^ Psychotropics and/or analgesics: G1: 61.8 G2: 37.9 Other co- morbidities, %: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: Problem drinking: G1: 32.3 G2: 51.7 Other psychiatric diagnoses: NR Health related QoL or functional status: NR
Author: Chamelian et al., 2004 See Chamelian and Feinstein, 2006 Country, Setting: Canada, tertiary care center Enrollment Period: NR Design: Cross-sectional Time from injury: 6 months Length of follow up: NA Dep. Scale/Tool: SCID | Inclusion criteria:; - 18 to 60 yrs old; - Non-penetrating mild or moderate TBI; Exclusion criteria: See inclusion criteria TBI Def: Mild TBI: GCS score of 13 to 15; LOC < 20 min; PTA < 24 hrs Moderate TBI: GCS score of 9 to 12; PTA > 24 hrs but less than 1 week | Group(s): G1: Participants with TBI and positive for the APOE-ɛ4 allele G2: Participants with TBI and negative for the APOE-ɛ4 allele N screened: NR N eligible: NR N included: G1: 19 G2: 71 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions, n (%): G1: 4 (21.1) G2: 12 (17.0) N with prior TBI (%): G1: 6 (31.6) G2: 16 (22.5)^*^ Age, yrs ± SD: G1: 31.2 ± 13.3 G2: 34.1 ± 12.3 Age ≥16, n (%): 90 (100) Global injury severity, AISS, mean ± SD: G1: 12.6 ± 9.5 G2: 13.5 ± 10.3 | Depression: SCID: DSM-IV criteria Other co-morbidities: PTSD: NR Other anxiety disorder: GHQ Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: GOS RHFUQ RPQ GHQ Resumption of work or studies | Depression, n (%): G1: 11 (18.2) G2: 51 (11.8) Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder: GHQ anxiety score, mean ± SD: G1: 2.2 ± 2.6 G2: 3.0 ± 2.7 Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: GOS score, 6 months, mean ± SD: G1: 4.3 ± 0.5 G2: 4.3 ± 0.6 RHFUQ score, 6 months, mean ± SD: G1: 17.9 ± 14.0 G2: 18.7 ± 13.7 RPQ score, 6 months ± SD: G1: 19.6 ± 18.2 G2: 24.6 ± 18.1 GHQ total score, 6 months, mean ± SD: G1: 7 ± 9.0 G2: 9.6 ± 8.6
Author: Chiu et al., 2006 Country, Setting: Taiwan, tertiary care hospitals Enrollment Period: January 2002 to June 2002 Design: Cross-sectional Time from injury, yrs ± SD: 1.0 ± 0.7 Length of follow up: NA Dep. Scale/Tool: CES-D | Inclusion criteria:; - Admission to one of 22 hospitals with diagnosis of TBI based on the ICD criteria; Exclusion criteria:; - Patient transferred from other hospital; TBI Def: Newly diagnosed TBI were identified by the presence among the discharge diagnoses of any of the following ICD-9 codes: 800–801.9, 803–804.9, and 850–854.9 Mild TBI: GCS score of 14 to 15 Moderate TBI: GCS score of 9 to 13 Severe TBI: GCS score of 3 to 8 | Group(s): Patients with TBI N screened: NR N eligible: 675 N included: 199 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR Depression status prior to TBI: NR N with prior TBI: NR Age, yrs ± SD: 45.4 ± 20.3 Age ≥16: NR Global injury severity: NR Severity of TBI, %: Severe: 7.5 Moderate: 22.6 Mild: 66.9 AIS-H score, %: 1–2: 52 3–4: 35.7 5: 12.2 Mechanism/type of injury, %: MVC: 58.1 Falls: 26.3 Violence: 7.1 Others: 8.6 | Depression: CES-D > 16 Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: GOS: Severe, Moderate, Good Cognition TICS: < 38: Impaired Functional Independence: Barthel Index (BI) 0–60: Severe dependence: 61–90: Moderate dependence 91–100: Mild/no dependence | Depression, %: 23.9 Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: GOS, %: Severe: 5.4 Moderate: 9.7 Good: 84.9 TICS, improvement, %: 25.6 Functional independence, %: Moderate/severe independence: 40.6 Mild/no independence: 59.5
Author: Curran et al., 2000 See Parcell et al., 2006; Perlesz et al., 2000 Country, Setting: Australia, rehabilitation center Enrollment Period: NR Design: Cross-sectional Time from injury: 1 to 5 years Length of follow up: NA Dep. Scale/Tool: BDI | Inclusion criteria:; - Received inpatient rehabilitation; Exclusion criteria: See inclusion criteria TBI Def: Severe concussion: Recovery of consciousness delayed; PTA 1–7 days^*^ | Group(s): G1: Patients with TBI G2: Patients with orthopedic injuries Ga: Male patients Gb: Female patients N screened: NR N eligible: NR N included: G1: 88 G1a: 61 G1b: 27 G2: 40 G2a: 22 G2b: 18 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, time of injury, yrs ± SD: G1: 33.7 ± 15.6 G2: 44.0 ± 18.0 Age ≥ 16, n (%): G1: NR G2: 40 (100) Global injury severity, days in inpatient and outpatient rehabilitation, mean ± SD: G1: 199.0 ± 181.0 G2: 112.0 ± 112.0 | Depression: BDI: NR Other co-morbidities: PTSD: NR Other anxiety disorder: STAI Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Coping Scale for Adults (CSA) Craig Handicap Assessment and Reporting Technique (CHART): 0: maximum degree of handicap 100: no handicap Rosenberg’s Self-Esteem Scale: 0–2: High 3–4: Medium 5–6: Low | Depression, %: Extremely severe: G1: 14.0 G2: 5.0 Severe: G1: 18.0 G2: 18.0 Mild to moderate: G1: 25.0 G2: 33.0 BDI score, mean ± SD: G1: 14.4 ± 11.3 G2: 12.3 ± 9.1 G1/G2: P = 0.33 G1a: 14.0 ± 11.1 G1b: 15.3 ± 12.0 G1a/G1b: P = 0.62 G2a: 13.8 ± 9.5 G2b: 10.6 ± 9.5 G2a/G2b: P = 0.29 Taking depression medications (%): NR Other co-morbidities: PTSD: NR Other anxiety disorder: STAI-state score, mean ± SD: G1: 41.9 ± 16.2 G2: 39.8 ± 14.3 G1a: 41.3 ± 14.9 G1b: 43.4 ± 19.2 G1a/G1b: P = 0.58 G2a: 44.5 ± 13.5 G2b: 33.5 ± 13.3 G2a/G2b: P = 0.02
Author: Deb and Burns, 2007 See Deb et al., 1999 & Deb et al., 1999 Country, Setting: UK, tertiary care center Enrollment Period: NR Design: Cross-sectional Time from injury: 12 months Length of follow up: NA Dep. Scale/Tool: SCAN, behavioral checklist | Inclusion criteria:; - A period of unconsciousness; - Evidence of fracture on skull X-rays; - Contusion or hemorrhage in CT or MRI brain scans; - Focal neurological signs; - A GCS score of less than 15; Exclusion criteria: See inclusion criteria TBI Def: According to ICD-9 codes | Group(s): G1: Patients with TBI aged 18 to 65 G2: Patients with TBI aged 65 and older N screened: NR N eligible: NR N included: G1: 120 G1: 45 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, mean: G1: 35.5 G2: 79.2 Age ≥16, n (%): 165 (100) Global injury severity: NR Severity of TBI, n (%): Minor: G1: 97 (81) G2: 38 (85) Moderate: G1: 16 (13) G2: 6 (13) Severe: G1: 7 (6) G2: 1 (2) | Depression: Reported as part of SCAN results; patients with ICD-10 code for depressive disorder Checklist of neurobehavioral symptoms, scored from 1 (most severe) to 6 (least severe); score of 1 to 4 indicates the presence of the symptom Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: Checklist of neurobehavioral symptoms Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: CIS-R, SCAN Checklist of neurobehavioral symptoms (listed in next column) Health related QoL or functional status: GOS ERSS GHQ-28: score of 11 or more is significant | Depression, SCAN, n (%): G1: 19 (16)^*^ G2: 5 (11)^*^ Depressed mood, checklist of neurobehavioral symptoms, n (%): G1: 27 (23) G2: 5 (11) Taking depression medications (%): NR Other co-morbidities, n (%): PTSD: NR Other anxiety disorder: NR Irritability: G1: 44 (37) G2: 14 (31) Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses, n (%): Mood swings: G1: 36 (30) G2: 10 (22) Sleep problems: G1: 44 (37) G2: 18(18) Slowness in thinking: G1: 15 (12) G2: 15 (33) Safety hazard: G1: 7 (6) G2: 8 (18) Fatigue: G1: 33 (27) G2: 6 (13)
Author: Deb, Lyons, and Koutzoukis, 1999 Deb, Lyons, Koutzoukis et al., 1999^ See Deb and Burns, 2007 Country, Setting: UK, tertiary care center Enrollment Period: July 1994 to June 1995 Design: Cross-sectional Time from injury: 1 year Length of follow up: NA Dep. Scale/Tool: SCAN, behavioral checklist | Inclusion criteria:; - At least 17 yrs old; - A period of unconsciousness; - Evidence of fracture on skull X-rays; - Contusion or hemorrhage in CT/magnetic resonance imaging scans; - Focal neurological signs; - A GCS score of less than 15; Exclusion criteria: See inclusion criteria TBI Def: Based on ICD-9 codes. Mild TBI: GCS of 13–15 Moderate TBI: GCS of 9–12 Severe TBI: GCS < 9 | Group(s): Patients with HI N screened: 346 N eligible: 196 N included: 164 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions, n:^ History of psychiatric illness: 28 N with prior TBI:^ 42 Age, median yrs (range): 43.5 (18–94) Age ≥16, n (%): 196 (100) Global injury severity: NR Severity of TBI, n: Mild: 134 Moderate/severe: 30 Mechanism/type of injury: NR Area of brain injured: NR Concomitant injuries: NR | Depression: SCAN: NR Depressed mood: based on checklist of neurobehavioral symptoms, scored from 1 (most severe) to 6 (least severe); score of 1 to 4 indicates the presence of the symptom Other co-morbidities: PTSD: NR Other anxiety disorder: SCAN Irritability: SCAN Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: SCAN Health related QoL or functional status: Not reported by depression status Edinburgh Rehab Status Scale (based upon GOS) | Depression, n (%): Severe/moderate: 15 (9) Moderate/mild: 17 (10.4) Depressive episode, n (%):^ 21 (12.8) Depressed mood, n (%): Mild TBI: 22 (16.3) Moderate/Severe TBI: 10 (33.3) Taking depression medications: NR Other co-morbidities, n (%): PTSD: NR Other anxiety Disorder: GAD:^ 3 (2.5) Irritability: Mild/Moderate: 35 (21.3) Severe/Moderate: 23 (14) Aggression: NR Suicidality: NR Substance use:^ Alcohol: 6 (4.9) Other psychiatric diagnoses: Panic disorder associated with depressive episode: 5 (NR) Psychiatric cases (CIS-R and PSQ): 28 (17)
Author: Dunlop et al., 1991 Country, Setting: US, other Enrollment Period: NR Design: Prospective cohort Time from injury: NR Length of follow up: At least 2 months Dep. Scale/Tool: Modified version of the NRS | Inclusion criteria:; - Evidence of deterioration (G1) or improvement (G2) of emotional or cognitive function between the time interval from 2 to 6 months postinjury; Exclusion criteria: See inclusion criteria TBI Def: NR^*^ | Group(s): G1: Patients with emotional or cognitive deterioration (an increase of 2 or more points in the total NRS score) G2: Patients with emotional improvement (a decrease of 2 or more points in the total NRS score) N screened: NR N eligible: 193 N included: G1: 34 G2: 34 N at conclusion: G1: 34 G2: 34 Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions, %: G1: 18 G2: 21 N with prior TBI: NR Age, yrs ± SD: G1: 34.6 ± 10.9 G2: 34.6 ± 9.8 Age ≥16: NR Global injury severity: NR | Depression: 10 item neurologic rating scale and 15 item neuropsychiatric rating scale, with scores ranging from 1–5: 5: Severe 1: No impairment Other co-morbidities: PTSD: NR Other anxiety disorder: Neuropsychiatric rating scale Irritability: NR Aggression: Neuropsychiatric rating scale Suicidality: NR Substance use: Positive Prior History of alcohol abuse Other psychiatric diagnoses: Past history Health related QoL or functional status: NR | Depression, %: Moderate to severe symptoms at 2–6 mos: G1: 57 G2: 44 Showing deterioration after 6 mos: G1: 28 G2: 0 Taking depression medications: NR Other co-morbidities, %: PTSD: NR Other anxiety disorder: Anxiety: Moderate to severe symptoms at 2–6 mos: G1: 33 G2: 47 Showing deterioration after 6 mos: G1: 26 G2: 0 Irritability: NR Aggression: Agitation/hostility: Moderate to severe symptoms at 2–6 mos: G1: 3 G2: 44 Showing deterioration after 6 mos: G1: 41 G2: 6 Suicidality: NR Substance use: NR
Author: Evans et al., 2005 Country, Setting: US, rehabilitation center Enrollment Period: December 1998 to March 2002 Design: Cross-sectional Time from injury: NR Length of follow up: NA Dep. Scale/Tool: CES-D | Inclusion criteria:; - Participation in the TBIMS research program funded by the National Institute for Disability and Rehabilitation Research; - Inclusion criteria for the TBIMS program are medically documented TBI, admission to an affiliated trauma center within 24 hours of injury, admission to the system inpatient BI program within 72 hours of discharge from the trauma center, aged 16 years or older, and provision of informed consent by the participant or legal proxy as appropriate; - Resolution of PTA prior to discharge from inpatient rehabilitation (to respond meaningfully to questionnaires); - Adequate language ability to respond to questionnaires; Exclusion criteria: See inclusion criteria | Group(s): Participants with TBI N screened: NR N eligible: NR N included: 96 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, median (IQR): 32 (22, 44) Age ≥16, n (%): 96 (100) Global injury severity, DRS, admission, mean (IQR): 11 (8,15) Severity of TBI, n (%): Severe: 55 (57) Moderate: 18 (19) Mild: 23 (24) Mechanism/type of injury, %: Whites (n=69): MVC: 79 Assault: 6.6 African-American (n=27): MVC: 58 Assault: 27 | Depression: CES-D: 16–20: Mild 21–26: Moderate ≥ 27: Severe Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Satisfaction With Life Scale (SWLS) ranges from 5 to 35 Disability Rating Scale (DRS) ranges from 0–30 Awareness Questionnaire (AQ) scale ranges from 17–85 | Depression, %: Severe: 25 Moderate: 12 Mild: 17 CES-D score, median (IQR): 17 (9,27) Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: AQ score, median (IQR): Clinician: Total: 32 (27,37) Cognitive: 12 (9,12) Behavioral: 11 (9,13) Motor: 9 (8,10) Patient: Total: 47 (40,53) Cognitive: 19 (16,22) Behavioral: 17 (15,20) Motor: 11 (9,12) Family: Total: 37 (31,44) Cognitive: 15 (12,17) Behavioral: 14 (11,16) Motor: 10 (8,10)
Author: Fann et al., 2009 See Fann et al., 2005; Bombardier et al., 2006;Bombardier et al., 2010 Country, Setting: US, trauma center Enrollment Period: July 2004 to October 2004 Design: Cross-sectional Time from injury, mean mos ± SD: 6.4 ± 3.7 Length of follow up: NA Dep. Scale/Tool: PHQ-9 | Inclusion criteria:; - At least 18 yrs old; - English speaking; - Hospitalized patients who sustained a traumatic injury to the head, with either the lowest GCS score ≤ 12 or radiological evidence of acute brain abnormality; - Resident of greater Puget Sound region (King, Pierce, Kitsap, Jefferson, Mason, Thurston, or Snohomish counties); Exclusion criteria:; - Homelessness (or no contact information available); - Incarceration; - A history of schizophrenia; - Participation in an investigational drug study; TBI Def: Complicated mild: GCS 13–15 and abnormal CT scan Moderate: GCS 9–12 Severe: GCS ≤ 8 | Group(s): Participants with TBI N screened: NR N eligible: 145 N included: 145 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions, n (%): Lifetime history of antidepressants: 54 (37.4) Lifetime history of outpatient mental health services: 21 (14.5) N with prior TBI (%): NR Age, yrs ± SD: 42.4 ± 18.3 Age ≥16, N (%): 145 (100) Global injury severity: NR Severity of TBI, n (%): Complicated mild: 89 (61.4) Moderate: 28 (19.3) Severe: 28 (19.3) | Depression: PHQ-9: Major depression based on DSM-IV criteria Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, PHQ-9, n (%): 37 (25.5) Taking depression medications (%): NR Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR
Author: Fann et al., 2005 See Bombardier et al., 2006; Fann et al., 2009; Bombardier et al., 2010 Country, Setting: US, trauma center Enrollment Period: April 2001 to November 2004 Design: Prospective cohort Time from injury: NR Length of follow up, mos: 12 Dep. Scale/Tool: PHQ-9, SCID, SCL- 20, HAM-D | Inclusion criteria:; - At least 18 yrs old; - English speaking; - Hospitalized patients who sustained a traumatic injury to the head, with either the lowest GCS score ≤ 12 or radiological evidence of acute brain abnormality; - Resident of greater Puget Sound region (King, Pierce, Kitsap, Jefferson, Mason, Thurston, or Snohomish counties); Exclusion criteria:; - Homelessness (or no contact information available); - Incarceration; - A history of schizophrenia; - Participation in an investigational drug study; TBI Def: Complicated mild: GCS of 13 to 15 Moderate: GCS of 9 to 12 Severe: GCS of ≤ 8 | Group(s): Patients with TBI N screened: NR N eligible: NR N included: 478 N at conclusion: 135 Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: 42.0 ± 16.8 (n=135) Age ≥16, n (%): 478 (100) Global injury severity: NR Severity of TBI, n (%): Severe: 34 (25.2) Moderate: 25 (18.5) Complicated mild: 76 (56.3) Mechanism/type of injury, n (%): MVC: 56 (41.5) Fall: 45 (33.3) Assault: 15 (11.1) Recreation/Sport: 7 (5.2) Other: 12 (8.9) Area of brain injured: NR | Depression: PHQ-9: ≥ 10, other criteria SCID:DSM-IV criteria; served as comparator for sensitivity/specificity analyses HAM-D SCL-20 Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, PHQ criteria, %: PHQ-9 score ≥ 10: 22.5 PHQ-9 score ≥ 10, at least one cardinal symptom scored ≥ 2: 16.3 At least five symptoms scored ≥ 2, at least one cardinal symptom: 11.6 At least five symptoms scored ≥ 1, at least one cardinal symptom: 24.1 At least one cardinal symptom scored ≥ 2: 20.5 Pearson’s correlations: PHQ-9, SCL-20: 0.8 (P < 0.001), n=39 0.9 (P < 0.001), n=138 PHQ-9, HAM-D: 0.7 (P < 0.001), n=39 0.8 (P < 0.001), n=138 Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR
Author: Fann et al., 1995 Country, Setting: US, TBI rehabilitation center Enrollment Period: September 1992 to December 1993 Design: Cross-sectional Time from injury, mos ± SD (range): 32.5 ± 35.1 (1–128) Length of follow up: NA Dep. Scale/Tool: DIS Version III-A | Inclusion criteria:; - Mild or moderate/severe TBI; Exclusion criteria: See inclusion criteria TBI Def: Based on ACRM criteria for mild and moderate/severe TBI Mild:; 1. LOC <30 mins; 2. PTA <24 hrs; 3. Focal neurologic deficits when severity does not differ from the following – LOC<30 mins, GCS 13–15 after 30 mins, PTA <24 hrs; Moderate/severe:; 1. GCS <13; 2. LOC >30 mins; 3. PTA >24 hrs; Head Injury Symptom Checklist includes subscale for patient self perceptions of injury | Group(s): G1: Current major depression G2: Current generalized anxiety disorder G3: Current non-depressed, non-anxious N screened: NR N eligible: 50 N included: G1: 13 G2: 12 G3: 29 N at conclusion: NA Depression, n (%): Major depression, prior to injury: 6 (12) At time of injury: NR Other preexisting psychiatric conditions, n (%): Psychiatric disorder: 25 (50) N with prior TBI: NR Age, yrs ± SD: G1+G2: 40.8 ± 13.5 G3: 35.9 ± 12.5 Total: 38.0 ± 13.0 Age ≥16: NR Global injury severity (ISS, RTS, etc.): NR | Depression: DIS: DSM-III-R criteria Other co-morbidities: PTSD: NR Other anxiety disorder: DSM-III-R Irritability: NR Aggression: NR Suicidality: NR Substance use: DSM-III-R Other psychiatric diagnoses: DSM-III-R Health related QoL or functional status: Medical outcomes health survey: (scored 0–100) Physical functioning: degree to which health limits physical activities Role functioning (physical): degree to which physical health limits work/daily activities. Role functioning (emotional): extent to which mental health interferes with daily activities Social functioning Bodily pain: effect of pain on work | Depression, n (%): Major depression: Current: 13 (26) After BI, resolved: 14 (28) Before BI: 6 (12) Lifetime: 33 (66) Taking depression medications (%): NR Other co-morbidities, n (%): PTSD: NR Other anxiety disorder: Current GAD: G1: 4/13 (30.8) Total: 12/50 (24.0) Current panic disorder: G1: 2/13 (15.4) Total: 2/50 (4.0) Current agoraphobia: G1: 0/13 Total: 1/50 (2.0) Irritability: NR Aggression: NR Suicidality: NR Current alcohol/drug use: G1: NR Total: 4/50 (8.0) Current dysthymia: G1: 5/13 (38.5) Total: 7/50 (14.0) Current bipolar disorder: G1: 0/13 Total: 0/50
Author: Federoff et al., 1992^ Jorge, Robinson, and Arndt, 1993^*^ Jorge, Robinson, Arndt, Starkstein et al., 1993^†^ See Jorge, Robinson, Arndt, Forrester et al., 1993; Jorge, Robinson, Starkstein, and Arndt, 1994; Jorge, Robinson, Starkstein, and Arndt, 1994 Country, Setting: US, trauma center Enrollment Period: NR Design: Prospective cohort Time from injury: NA Length of follow up: 12 mos Dep. Scale/Tool: DSM-III-R, HAM-D, PSE | Inclusion criteria:; - Shock trauma admissions with acute closed head injury; Exclusion criteria:; - Penetrating head injuries or associated spinal cord injury; - Multiple system involvement such as fractures which would influence physical recovery or produce significant secondary brain damage as a result of hypovolemic shock or severe hypoxia (abdominal hemorrhages or lung collapse); - Decreased level of consciousness (drowsy, stuporous, or comatose) or delirium; - Aphasic disorders (unable to follow a two-stage command) that interfered with comprehension of questions | Group(s): G1^^*^: Patients with major depression G1^†^: Patients with major or minor depression G2: Nondepressed patients N screened: NR N eligible: NR N included: G1^^*^: 17 G1^†^: 19 G2: 47 N at conclusion: G1^^*^: 17 G1^†^: 19 G2: 47 Depression, n: Prior to injury: 0 At time of injury: 0 Other preexisting psychiatric conditions: Personal history of psychiatric disorder, %: G1^: 71 G1^*^: 24 G1^†^: 68 G2^†^^: 37 G2^*^: 13 Personal history of alcohol or drug abuse, n (%):^*^ G1: 8 (47) G2: 11 (23) N with prior TBI: NR Age, median yrs (IQR):^†^ G1: 25 (8.0) G2: 27 (13.5) | Depression: Patient self-report of depressed mood; structured initial psychiatric evaluation at 1 month post-TBI with assessment for DSM-III criteria for depression; Hamilton Depression Rating Scale (HAM-D); Present State Examination (PSE) 5 DSM-III-R symptoms significantly different between depressed and non depressed patients and used for discriminatory analysis: suicidal ideation, inappropriate guilt, anergia, psychomotor agitation, weight loss/poor appetite Other co-morbidities: PTSD: NR Other anxiety disorder: PSE, DSM-III-R Irritability: DSM-III-R Aggression: NR Suicidality: DSM-III-R Substance use: Patients queried regarding personal history of alcohol and other substance abuse | Depression, %: Initial evaluation: Mood:^†^ 19 Major:^^*^ 17 Minor:^^*^ 2 3 months: Mood:^†^ 16 Major:^^*^ 12 Minor:^^*^ 4 6 months: Mood:^†^ 12 Major:^^*^ 10 Minor:^^*^ 1 12 months: Mood:^†^ 11 Major:^^*^ 8 Minor:^^*^ 3 Depression, incidence, n (%): 3 months: Major: 4/38 (10) Minor: 3/38 (8) 6 months: Major: 4/27 (15) Minor: 0/27 (0) 12 months: Major: 3/25 (12) Minor: 1/25 (4) DSM-III-R symptoms, median (IQR):^^*^ Initial evaluation: G1: 3 (3–3.25) G2: 0 (0–1) 3 months: G1: 4 (3–5) G2: 0 (0–1) 6 months: G1: 4 (3–4) G2: 0 (0–1) 12 months: G1: 4 (3.5–4) G2: 0 (0–0) HAM-D score, initial evaluation, median (IQR):^†^ G1: 13 (5) G2: 7 (3)
Author: Felde et al., 2006 Country, Setting: US, psychiatric/specialty center Enrollment Period: NR Design: Cross-sectional Time from injury: NR Length of follow up: NA Dep. Scale/Tool: DSM III-R, BDI, HAM-D | Inclusion criteria:; - Voluntary, sequential adult patients enrolled in a university substance abuse program; Exclusion criteria: See inclusion criteria TBI Def: A trained research associate at the master’s level made an assessment regarding the presence or absence of TBI with unconsciousness during adulthood, asking “As an adult, have you ever been unconscious as the result of a head injury?” | Group(s): G1: Patients with prior TBI G2: Patients without prior TBI N screened: 550 N eligible: 550 N included: G1: 218 G2: 332 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: G1: 218 G2: 0 Age, yrs ± SD: G1: 30.2 ± 8.7 G2: 31.8 ± 11.1 Age ≥ 16, n (%): 550 (100) Global injury severity: NR Severity of TBI: NR Mechanism/type of injury: NR Area of brain injured: NR | Depression: DSM III-R: NR BDI: NR HAM-D: NR Other co-morbidities: PTSD: NR Other anxiety disorder: HAM-A Irritability: NR Aggression: NR Suicidality: BPRS Substance use: MN-SAPS (clinician-rated scale) MAST/AD (self-rated scale) Other psychiatric diagnoses: BPRS Health related QoL or functional status: NR | Depression, n (%): Depressive disorder: G1: 34 (16) G2: 55 (17) G1/G2: P = 0.854 BDI score, mean ± SD: G1: 19.9 ± 11.8 G2: 18.1 ± 12.2 G1/G2: P = 0.106 HAM-D score, mean ± SD: G1: 18.3 ± 11.2 G2: 15.8 ± 10.8 G1/G2: P = 0.009 Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder, n (%): G1: 12 (6) G2: 20 (6) G1/G2: P = 0.954 HAM-A score, mean ± SD: G1: 14.6 ± 9.2 G2: 12.9 ± 8.8 G1/G2: P = 0.032 Irritability: NR Aggression: NR Suicidality: Suicide Attempt Ever: G1: 101 (48) G2: 120 (37) G1/G2: P = 0.019 Substance abuse diagnosis, n (%): G1: 217 (100) G2: 331 (100)
Author: Franulic et al., 2004 Country, Setting: Chile, trauma center Enrollment Period: NR Design: Cross-sectional Time from injury: 2–10 years Length of follow up: NA Dep. Scale/Tool: HAM-D | Inclusion criteria: See exclusion criteria Exclusion criteria:; - Concomitant pathologies (paraplegia after spinal cord injury, amputations, etc.); - Living outside the hospital catchment area; TBI Def: NR^ | Group(s): G1: TBI patients 2 years postinjury G2: TBI patients 5 years postinjury G3: TBI patients 10 years postinjury N screened: NR N eligible: NR N included: G1: 71 G2: 73 G3: 58 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, mean^*^: G1: 37.9 G2: 41.8 G3: 37.2 Age ≥16: NR Global injury severity: NR Severity of TBI, %: Mild TBI: G1: 71.4 G2: 59.1 G3: NR | Depression: HAM-D: NR Other co-morbidities: PTSD: NR Other anxiety disorder: HAM-A Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Employed vs. unemployed NRS-R | Depression, HAM-D score, mean ± SD^†^: G1: 12.0 ± 6.1 G2: 14.0 ± 7.5 G3: 14.6 ± 8.9 Depressive symptoms, %: G1: 42.3 G2: NR G3: 59.3 Taking depression medications (%): NR Other co-morbidities: PTSD: NR Other anxiety disorder: HAM-A score, mean ± SD^†^: G1: 19.7 ± 8.5 G2: 20.5 ± 9.2 G3: 18.1 ± 9.7 Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Employed, %: G1: 53.5 G2: 55.6 G3: 69 NRS-R score, mean ± SD: G1: 47.0 ± 9.1 G2: 25.3 ± 9.1 G3: 49.2 ± 11.6
Author: Frenisy et al., 2006 Country, Setting: France, tertiary care center Enrollment Period: 1998 to 2000 Design: Cross-sectional Time from injury, yrs ± SD: G1: 1.02 ± 0.39 G2: 0.93 ± 0.41 Length of follow up: NA Dep. Scale/Tool: NRS-R, SCL 90-R | Inclusion criteria:; - Admitted patients were selected in alphabetical order; - G1: Aged 18 to 40 years and a severe, isolated BI with a rated GCS score ≤ 8 and/or have undergone brain surgery within the first 6 hours without any serious associated lesions, or minor lesions associated without long-term extra cranial consequences; - G2: Aged between 18 and 50 years and had to exhibit a multiple trauma with no associated severe or moderate BI; Exclusion criteria:; - Patients with severe or incapacitating pathologies with psychiatric antecedents; - Patients whose injuries were self-inflicted; - Patients who exhibited medullar lesions; TBI Def: NR^*^ | Group(s): G1: Patients with severe brain injuries G2: Patients with multiple trauma N screened: G1: 486 G2: 111 N eligible: G1: 486 G2: 111 N included: G1: 25 G2: 25 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: G1: 26.1 ± 9.6 G2: 33.8 ± 10.4 Age ≥ 16, n (%): 50 (100) Global injury severity, ISS score, mean ± SD: G1: 25.4 ± 10.8 G2: 22.0 ± 10.1 Severity of TBI, GCS score, mean ± SD: G1: 6.6 ± 1.2 G2: 14.2 ± 2.2 | Depression: NRS-R: NR SCL 90-R: NR Other co-morbidities: PTSD: NR Other anxiety disorder: NRS-R SCL 90-R Spielberger’s State-Trait Anxiety Scale Irritability: NRS-R Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NRS-R SCL 90-R Health related QoL or functional status: NR | Depression, NRS-R, n (%): G1: 19 (76) G2: 19 (76) SCL 90-R, depression score, mean ± SD: G1: 9.7 ± 9.1 G2: 9.4 ± 7.8 Taking depression medications, n (%): G1: 2 (8) G2: 0 Other co-morbidities: PTSD: NR Other anxiety disorder: Anxiety NRS-R, n (%): G1: 17 (68) G2: 21 (84) SCL 90-R, anxiety score, mean ± SD: G1: 5.2 ± 7.4 G2: 4.7 ± 4.6 Spielberger’s State score, mean ± SD: G1: 39.4 ± 16.8 G2: 37.7 ± 13.2 Spielberger’s Trait score, mean ± SD: G1:44.9 ± 15.4 G2:41.8 ± 12.3 Irritability, n (%): G1: 20 (80) G2: 13 (52) Aggression: NR Suicidality: NR Substance use: NR
Author: Gagnon et al., 2006 Country, Setting: Canada, rehabilitation center Enrollment Period: 1986 to 2000 Design: Cross-sectional Time from injury, yrs ± SD: G1: 3.3 ± 3.15 G2: NA Length of follow up: NA Dep. Scale/Tool: BDI | Inclusion criteria:; - TBI occurring at or above the age of 16; - Younger than 60 yrs old at time of study; - Moderate or severe TBI diagnosis; - TBI occurred at least 1 year prior to the study in order to ensure that post-TBI behavioral changes were stable; - Subjects had to show sufficient motor, language, perceptual and memory skills to allow for valid testing; - Subjects had to be living in the community (none were hospitalized); Exclusion criteria:; - Pre-TBI neurological or psychiatric history of an axis II personality disorder in the medical records | Group(s): G1: Participants with TBI G2: Participants matched by gender, age, and education N screened: 169 N eligible: 83 N included: G1: 30 G2: 30 N at conclusion: NA Depression: Prior to injury: G1: 4 (13) G2: NR At time of injury: NR Other preexisting psychiatric conditions: G1: 3 (10) G2: 4 (13) N with prior TBI: G1: 0 G2: 0 Age, yrs ± SD: G1: 36.3 ± 13.1 G2: 36.3 ± 13.3 Age ≥ 16, n (%): 60 (100) Global injury severity: NR Severity of TBI, n (%) Severe: G1: 17 (56.7) Moderate: G1: 14 (43.3) | Depression: BDI: NR Other co-morbidities: PTSD: NR Other anxiety disorder: Diagnostic Interview for Borderlines (DIB) Irritability: NR Aggression: NR Suicidality: NR Substance use: DIB Other psychiatric diagnoses: NR Health related QoL or functional status: Interpersonal features: DIB | Depression, n (%): Severe: G1: 1 (3) Moderate-severe: G1: 4 (13) Mild-moderate: G1: 2 (7) Minimal: G1: 6 (20) BDI score, mean ± SD: G1: 10.5 ± 8.0 G2: 2.7 ± 4.0 G1/G2: P < 0.001 DIB-R, chronic major depression, n (%): G1: 15 (50) G2: 1 (3.3) G1/G2: P < 0.0001 DIBR/BDI, correlation coefficient: DT: G1: 0.6 (P = 0.001) G2: 0.5 (P = 0.01) DA: G1: 0.5 (P = 0.01) G2: 0.1 (P = NS) DC: G1: 0.2 (P = NS) G2: 0.2 (P = NS) DI: G1: 0.4 (P = 0.05) G2: 0.7 (P = 0.001) DR: G1: 0.5 (P = 0.01) G2: 0.4 (P = 0.05) Taking depression medications during testing, n (%): Anti-convulsive or anti-depressive: 19 (63.3)
Author: Gass et al., 1991 Country, Setting: US, other Enrollment Period: NR Design: Cross-sectional Time from injury, yrs ± SD: 1.1 ± 1.3 Length of follow up: NA Dep. Scale/Tool: MMPI | Inclusion criteria:; - No history of substance abuse or emotional disturbance; - Within 5 years of injury; Exclusion criteria: See inclusion criteria TBI Def: NR | Group(s): Males with closed head trauma N screened: NR N eligible: NR N included: 58 N at conclusion: NA Depression: Prior to injury: None (see inclusion criteria) At time of injury: None (see inclusion criteria) Other preexisting psychiatric conditions: None (see inclusion criteria) N with prior TBI: NR Age, yrs ± SD: 34.9 ± 13.7 Age ≥ 16: NR Global injury severity: NR Severity of TBI, LOC, %: > 1 week: 17 1–7 days: 11 < 24 hrs: 72 Mechanism/type of injury: NR | Depression: MMPI: depression (D) scale > 69 Harris-Lingoes subjective depression (D1) subscale > 69 Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: MMPI subscale Health related QoL or functional status: NR | Depression, MMPI, %: Original profile: 53 Adjusted profile: 36 Depression, Harris-Lingoes (D1) subscale, %: 22 MMPI depression (D) score, mean ± SD: Original profile: 70.8 ± 14.5 Adjusted profile: 63.8 ± 13.5 Harris-Lingoes subjective depression (D1) score, mean ± SD: 59.1 ± 13.0 Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: Schizophrenia, MMPI, %: Original profile: 43 Adjusted profile: 12 MMPI schizophrenia score, mean ± SD: Original profile: 68.3 ± 15.0 Adjusted profile: 57.8 ± 10.3
Author: Ghaffar et al., 2006 Country, Setting: Canada, tertiary care centers Enrollment Period: NR Design: Cross-sectional Time from injury: 6 months Length of follow up: NA Dep. Scale/Tool: GHQ, RPCQ | Inclusion criteria:; - 16 to 60 yrs of age; Exclusion criteria:; - Major medical illness such as cardiac or cerebrovascular disease; TBI Def: According to ACRM criteria | Group(s): G1: Patients with mTBI randomly assigned for assessment and treatment 1 week post-injury G2: Patients with TBI not offered follow up and treatment Ga: Depressed patients (GHQ ≥ 1) Gb: Nondepressed patients (GHQ = 0) N screened: NR N eligible: NR N included: G1: 86 G2: 84 Ga: 35 Gb: 87 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions, %: Psychiatric illness: 22.9 N with prior TBI, n (%): 52/170 (30.6) Age, yrs ± SD: G1: 30.7 ± 10.9 (n=97) G2: 33.3± 12.4 (n=94) | Depression: GHQ: depression subscale ≥ 1 RPCQ: depression questions Other co-morbidities: PTSD: NR Other anxiety disorder: GHQ Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Cognitive testing (Stroop Color-Word test, Symbol-Digit Modalities test, The Paced Visual Serial Addition Task, Simple Reaction time, Choice Reaction time, Hopkins Verbal-Learning test, The Vocabulary subset and Letter-Number Sequencing, The Matrix-Reasoning subset of the WAIS-III) RFQ GHQ: social dysfunction subscale and somatic concern subscale | Depression, GHQ, n (%): 35/122 (28.7) GHQ total score^*^, mean ± SD: G1: 6.6 ± 7.6 G2: 6.8 ± 7.9 RPCQ total score^*^, mean ± SD: G1: 17 ± 18 G2: 16.3 ± 15.9 Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder: GHQ: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: RFQ total score, mean ± SD: G1: 10.9 ± 11.5 G2: 10.6 ± 12.0 Stroop Symbol-Digit Modalities, seconds ± SD: Ga: 12.4 ± 3.5 Gb: 10.5 ± 1.8 Ga/Gb: P = 0.01
Author: Gomez-Hernandez et al., 1997 Country, Setting: Spain, tertiary care center Enrollment Period: NR Design: Prospective cohort Time from injury to first assesment, median days (IQR): 31 (32) Length of follow up: 12 months Dep. Scale/Tool: DSM-IV | Inclusion criteria:; - Older than 18 years; - Predominant injury involving head trauma; - Closed head injury; Exclusion criteria:; - Penetrating head injuries; - Associated spinal cord injury; - Multiple non-CNS involvement which would have influenced the course of their recovery (e.g., multiple fractures) or would have led to significant secondary brain damage as a result of severe hypotension or hypoxia (e.g., intra-abdominal hemorrhages, collapsed lungs, etc); - A decreased level of consciousness, disorientation or deliriousness, or had aphasic disorders that would interfere with the psychiatric interview; TBI Def: NR^*^ | Group(s): G1: Depressed patients with TBI G2: Non-depressed patients with TBI N screened: NR N eligible: NR N included: G1: 23 G2: 42 N at conclusion: G1: 10 G2: 27 Depression, n: Prior to injury: 0 At time of injury: 0 Other preexisting psychiatric conditions, n (%): History of alcohol or drug abuse: 30 (46.1) History of psychiatric disorder without alcohol or drug abuse: 9 (13.8) N with prior TBI: NR Age, yrs ± SD: G1: 27.3 ± 8.4 G2: 29.3 ± 10.3 Age ≥16, n (%): 65 (100) Global injury severity: NR | Depression: DSM-IV criteria Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Social Functioning Exam (SFE): A semi-structured clinical interview that assesses the patient’s satisfaction with his or her social functioning. It consists of 28-items that are rated at 0=normal functioning, 1=moderate impairment, 2=severe impairment. | Depression, initial evaluation, n (%): Major depression: 19/65 (29) Minor depression: 4/65 (6) Depression, 3 months, n (%): Major depression: 10/48 (21) Minor depression: 8/48 (15) Depression, 6 months, n (%): Major depression: 12/42 (28) Minor depression: 4/42 (9) Depression, 9 months, n (%): Major depression: 5/43 (12) Minor depression: 9/43 (21) Depression, 1 year, n (%): Major depression: 8/37 (22) Minor depression: 2/37 (5) Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder: NR Substance use: NR Irritability: NR Aggression: NR Suicidality: NR
Author: Gordon, Brown et al., 1998 See Sliwinski et al., 1998 Country, Setting: US, other Enrollment Period: 1993 to 1997 Design: Cross-sectional Time from injury, yrs ± SD: G1: 14.7 ± 9.3 G2: 7.9 ± 7.9 G3: 14.2 ± 11.8 G4: NA Length of follow up: NA Dep. Scale/Tool: BDI | Inclusion criteria:; - 18 to 65 yrs old; - Reside in a noninstitutional community setting; - At least 1 year postinjury; Exclusion criteria: See inclusion criteria TBI Def: Hidden TBI: A blow to the head that, at a minimum, resulted in a dazed and confused state, but is not used as an explanatory principle in an individual’s life (i.e. the individual does not identify themselves as a person with TBI) | Group(s): G1: Participants with hidden TBI G2: Participants with mild TBI G3: Participants with head trauma G4: Participants with no disability N screened: G1: 143 G2-G4: 430 N eligible: G1: 21 G2-G4: 430 N included: G1: 21 G2: 21 G3: 21 G4: 21 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: G1: 37.6 ± 11.8 G2: 38.3 ± 11.2 G3: 37.4 ± 12.1 G4: 37.9 ± 12.1 Age ≥16, n (%): 451 (100) Global injury severity: NR | Depression: BDI > 15 Other co-morbidities: PTSD: NR Other anxiety disorder: Subjective self reported feeling of anxiousness Irritability: Subjective self reported feeling of irritability Aggression: NR Suicidality: NR Substance use: Bigelow Quality of Life Questionnaire: negative consumption of alcohol and drugs Reported use of Alcoholics Anonymous or other 12-step program Other psychiatric diagnoses: NR Health related QoL or functional status: Bigelow quality of life questionnaire Community Integration Questionnaire (CIQ) Craig Handicap Assessment Capacity Technique (CHART) | Depression, %: G1: 23.8 G2: 28.6 G3: 4.8 G4: 0 BDI score, mean ± SD: G1: 10.2 ± 6.1 G2: 11.5 ± 10.1 G3: 3.4 ± 5.1 G4: 2.2 ± 2.8 G2/G4: P < 0.003 Taking depression medications: NR Other co-morbidities: NR PTSD: NR Other anxiety disorder: G1: 57.1 G2: NR G3: NR G4: 0 Irritability: G1: 57.1 G2: NR G3: NR G4: 0 Aggression: NR Suicidality: NR Substance use: Bigelow quality of life questionnaire, mean score ± SD: Negative consumption alcohol: G1: 53.1 ± 3.8 G2: 55.0 ± 0 G3: 54.4 ± 1.8 G4: 55.0 ± 0
Author: Gordon, Sliwinski et al., 1998 See Sliwinski et al., 1998 Country, Setting: US, other Enrollment Period: 1993 to 1997 Design: Cross-sectional Time from injury (yrs): G1: 11.2 G2: 9.1 G3: NA G4: NA Length of follow up: NA Dep. Scale/Tool: BDI | Inclusion criteria:; - 18 to 65 yrs old; - Reside in non-institutional community setting; - At least 1 year postinjury; - Exercise (jogging, swimming, biking) for at least 30 mins three times a week for at least the preceding 6 months; Exclusion criteria: See inclusion criteria TBI Def: NR | Group(s): G1: TBI exercise group G2: TBI non-exercise group G3: Non-TBI exercise group G4: Non-TBI non-exercise group N screened: G1+G2: 430 G3+G4: 287 N eligible: G1: 64 G2: 176 G3: 66 G4: 73 N included: G1: 64 G2: 176 G3: 66 G4: 73 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: G1: 37.8 ± 10.3 G2: 37.1 ± 10.0 G3: 38.3 ± 12.7 G4: 39.0 ± 11.3 Age ≥16, n (%): 379 (100) Global injury severity: NR | Depression: BDI > 15 Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: TIRR SF-36 | Depression, %: G1: 12.5 G2: 33.7 G3: 6.1 G4: 6.8 G1+G2/G3+G4: P < 0.0001 G1+G3/G2+G4: P < 0.01 BDI score, mean ± SD: Total: G1: 7.8 ± 7.1 G2: 13.9 ± 10.6 G3: 4.1 ± 5.3 G4: 5.4 ± 5.6 Somatic items: G1: 2.9 ± 2.7 G2: 5.0 ± 3.9 G3: 1.3 ± 2.2 G4: 2.0 ± 2.1 Non-somatic items: G1: 5.4 ± 5.3 G2: 8.8 ± 7.21 G3: 2.7 ± 4.2 G4: 3.4 ± 4.3 Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR
Author: Hawley and Joseph, 2008 Setting: UK, rehabilitation centers Enrollment Period: 1991 to 1997 Design: Prospective cohort Time from injury, months ± SD: G1: 4.65 ± 4.63 G2: 13.67 ± 17.92 G3: 19.83 ± 26.22 Length of follow up: 10 years Dep. Scale/Tool: HADS, structured questionnaire | Inclusion criteria:; - 16 to 65 yrs old; - Traumatic brain injury; Exclusion criteria:; - Non-traumatic brain injury, including subarachnoid hemorrhage; TBI Def: Mild BI: LOC for 15 minutes or less and/or a GCS of 13 to 15 Moderate BI: LOC for more than 15 minutes but less than 6 hours or a PTA of less than 24 hours and/or GCS of 9 to 12 Severe BI: LOC for 6 hours or more or a PTA of 24 hours or more and/or GCS of 6 to 8 Very severe BI: LOC for 48 hours or more or a PTA of 7 days or more and/or GCS of 3 to 5 | Group(s): G1: Patients with mild TBI G2: Patients with moderate TBI G3: Patients with severe TBI N screened: NR N eligible: 563 N included: G1: 38 G2: 24 G3: 103 N at conclusion: G1: 38 G2: 24 G3: 103 Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, 10 year follow up, yrs ± SD (range): 45.5 ± 13.57 (26–79) Age ≥16, n (%): 165 (100) Global injury severity: NR Severity of TBI, %: Mild: 23 Moderate: 14.5 Severe: 62.4 | Depression: HADS: 11–21: cases 8–10: borderline 0–7: non-cases 10 year questionnaire: Frequent Occasional None Other co-morbidities: PTSD: NR Other anxiety disorder: HADS Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: GOSE FIM + FAM COS CiOP | Depression, HADS, 6 months, n (%): Cases: G1: 3/8 (37.5) G2: 3/12 (25) G3: 10/58 (17.2) Borderline: G1: 0/8 (37.5) G2: 0/12 (25) G3: 17/58 (29.3) Depression, 10 years, n (%): Frequent: G1: 6/38 (15.8) G2: 10/24 (41.7) G3: 22/103 (21.4) Occasional: G1: 20/38 (52.6) G2: 9/24 (37.5) G3: 44/103 (42.7) Taking depression medications (%): NR Other co-morbidities, n (%): PTSD: NR Other anxiety disorder: Anxiety, HADS, 6 months: Cases: G1: 2/8 (25) G2: 4/12 (33.3) G3: 19/58 (32.8) Borderline: G1: 2/8 (25) G2: 1/12 (8.3) G3: 10/58 (17.2) Anxiety, HADS, 10 years: Frequent: G1: 8/38 (21.1) G2: 6/24 (25) G3: 21/99 (21.2) Occasional: G1: 17/38 (44.7) G2: 12/24 (50) G3: 38/99 (38.4)
Author: Hawthorne et al., 2009 Country, Setting: Australia, trauma center Enrollment Period: NR Design: Cross-sectional Time from injury, median mos (range): 32 (3–136) Length of follow up: NA Dep. Scale/Tool: HADS, PRIME-MD | Inclusion criteria:; - At least 15 yrs old at time of injury; - 3 mos to 15 yrs since injury; - Available GCS 24 hr worst score; - Diagnosis of TBI according to ICD-10; - Able to consent; Exclusion criteria:; - GOS-E ≤3; - Spinal cord injury; - Presence of significant current or pre-injury psychiatric conditions or ongoing severe addiction; - Inability to understand, cooperate, and answer questions in English; - Terminal illness; - Major trauma, including life-threatening accident, rape or other sexual molestation, assault with serious physical injury, torture or kidnap, or having suffered a serious illness | Group(s): G1: Participants with TBI randomly selected from trauma registry G2: Matched participants without TBI N screened: NR N eligible: 203 N included: G1: 66 G2: 66 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI (%): NR Age, yrs ± SD: 39 ± 15 Age ≥16, N (%): NR Global injury severity, n (%): General health: G1: Excellent: 3 (4.5) Very good: 25 (37.9) Good: 24 (36.4) Fair/poor: 14 (21.2) G2: Excellent: 15 (22.7) Very good: 24 (36.4) Good: 17 (25.8) Fair/poor: 10 (15.2) | Depression: HADS (G1): >8 indicates probable morbidity PRIME-MD (G2): Major depression Other co-morbidities: PTSD: NR Other anxiety disorder: HADS Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: SF-36 | Depression, HADS, n (%): G1: 15 (22.7) PRIME-MD, n (%): G2: 2 (3.0) Taking depression medications (%): NR Other co-morbidities, %: PTSD: NR Other anxiety disorder: G1: 36 Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: SF-36 summary scales, mean ± SD:: Physical: G1: 48.0 ± 9.7 G2: 52.3 ± 9.0 P < .0.01 Mental: G1: 43.3 ± 10.7 G2: 51.0 ± 9.6 P < 0.01 Multivariate model predictors: Injury severity (GCS score, coma length, PTA duration) did not predict risk of depression
Author: Herrmann et al., 2009 Country, Setting: Canada, tertiary care center Enrollment Period: October 2003 to April 2007 Design: Cross-sectional Time from injury, d ± SD : 113.6 ± 92.7 Length of follow up: NA Dep. Scale/Tool: SCID | Inclusion criteria:; - Mild-to-moderate TBI within 1 yr; Exclusion criteria:; - Prior TBI; - A significant acute medical illness; - Presence of premorbid psychiatric diagnosis of schizophrenia, dementia, or bipolar disorder; TBI Def: Based on ACRM criteria Mild: LOC <30 mins, GCS score at the emergency room of 13–15, duration of PTA <24h, and negative CT scan results Moderate: GCS score of 9–12 and PTA <1 wk Patients with indices of GCS score and PTA in the mild range who had focal injuries coded on their head CT were also categorized as moderate Severe: NR | Group(s): Participants with TBI N screened: NR N eligible: NR N included: 200 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI (%): None, see exclusion criteria Age, yrs ± SD: Depressed: 37.4 ± 16.3 Nondepressed: 37.5 ± 17.8 Age ≥16, N (%): NR Global injury severity: NR Severity of TBI, n (%): Mild: 90 (45.0) Moderate: 110 (55.0) Mechanism/type of injury: NR Area of brain injured: NR Concomitant injuries: NR | Depression: SCID: Based on DSM-IV criteria Major depression-like episode: 5/9 categories of depression module met Depressive features: Not meeting full criteria, but with a predominant mood of “depressed” or answering positively to being depressed or down most of the day nearly every day for at least 2 weeks in the last month Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: RPCQ Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, n (%): 96 (48.0) Taking depression medications (%): NR Other co-morbidities, n (%): PTSD: NR Other anxiety disorder: NR Irritability: 91/96 (94.8) reporting mild to severe symptoms Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR
Author: Hibbard et al., 2004 See Ashman et al., 2004 Country, Setting: US, tertiary care center Enrollment Period: March 1995 to December 2000 Design: Prospective cohort Time from injury, yrs ± SD: G1: 2.51 ± 1.3 G2: 2.63 ± 1.3 G3: 2.52 ± 1.2 G4: 2.16 ± 0.5 Length of follow up: 1 year Dep. Scale/Tool: SCID, BDI | Inclusion criteria:; - Between the ages of 18 and 87; - Self-identified TBI; - Between 3 months and 4 years postinjury; - Residents of the United States living within the community; - Capable of giving informed consent for participation and answering interviews independently; Exclusion criteria:; - The presence of an acquired brain injury (e.g., cerebrovascular accident, aneurysm); - A preexisting neurocognitive disorder; - Any preexisting psychotic disorder (e.g., schizophrenia, psychoses not otherwise specified, depression with psychotic features); TBI Def: According to ACRM criteria^ | Group(s): G1: Patients experiencing no depression after TBI G2: Patients with resolved depression after TBI G3: Patients with late-onset depression after TBI G4: Patients with chronic depression after TBI N screened: NR N eligible: NR N included: G1: 91 G2: 52^*^ G3: 19 G4: 27 N at conclusion: G1: 91 G2: 52^*^ G3: 19 G4: 27 Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions, %: Mood disorders: 24 Substance abuse: 22 Anxiety: 9 Eating disorders: 1 N with prior TBI: NR Age, yrs ± SD: G1: 43.8 ± 16.7 G2: 43.1 ± 14.7 G3: 38.5 ± 17.9 G4: 44.8 ± 10.0 | Depression: SCID: No depression: Did not meet DSM-IV criteria for major mood disorder at either T1 (time 1=initial screening) or T2 (time 2= 1 year following initial screening). Resolved depression: Diagnosed with major depression at T1 resolved by T2. Late-onset-depression: Not depressed at T1 but met the criteria for DSM-IV diagnoses of major depression at T2. Chronic depression: Met the DSM-IV criteria for major depression at both T1 and T2. BDI: used to measure depression severity at T1 and T2 Other co-morbidities: PTSD: NR Other anxiety disorder: DSM-IV Irritability: NR Aggression: NR Suicidality: NR Substance use: DSM-IV Other psychiatric diagnoses: DSM-IV | Depression, n: Chronic depression: 27 Late onset depression: 19 Resolved depression: 52^*^ No depression: 91 Taking depression medications (%): NR Other co-morbidities: PTSD: NR Other anxiety Disorder, %: Initial screening: 19 1 year follow-up: 16 Irritability: NR Aggression: NR Suicidality: NR Substance use, %: Initial screening: 4 1 year follow-up: 6 Other psychiatric diagnoses: Co-occurring psychiatric disorder, initial screening, n (%): G1: 47 (52) G2: 23 (44) G3: 14 (74) G4: 7 (26) Co-occurring psychiatric disorder, 1 year follow-up, n (%): G1: 48 (53) G2: 38 (73) G3: 16 (84) G4: 25 (93)
Author: Hibbard et al., 1998 See Sliwinski et al., 1998 Country, Setting: US, other Enrollment Period: NR Design: Cross-sectional Time from injury, years: 7.6 Length of follow up: NA Dep. Scale/Tool: SCID | Inclusion criteria:; - 18 to 65 yrs old At least 1 year post-TBI; - Resident of New York state and living within the community; Exclusion criteria:; - Non-traumatic brain injuries (brain tumors, stroke, etc.); TBI Def: NR | Group(s): Patients with TBI G1: Patients with pre-TBI Axis I diagnosis G2: Patients with no pre-TBI Axis I diagnosis N screened: 431 N eligible: 100 N included: G1: 51 G2: 49 N at conclusion: NA Depression: Prior to injury, n (%):17 (17) At time of injury: NR Other preexisting psychiatric conditions, n (%): Dysthymia: 1 (1) PTSD: 6 (6) OCD: 1 (1) Panic disorder: 4 (4) Phobias: 4 (4) Substance use disorder: 40 (40) One Axis 1 disorder: 34 (34) Two or more Axis 1 disorders: 17 (17) Depression status prior to TBI: NR N with prior TBI: NR Age, yrs: 39.8 ± 10.2 | Depression: SCID: DSM-IV criteria Other co- morbidities: PTSD: SCID Other anxiety disorder: SCID Irritability: NR Aggression: NR Suicidality: NR Substance use: SCID Other psychiatric diagnoses: SCID Health related QoL or functional status: NR | Depression, post- TBI, n (%): MDD: 61 (61) MDD with psychotic features: 14 (14) Dysthymia: 3 (3) Depression, onset post-TBI, n (%resolved): MDD: G1: 16 (69) G2: 32 (59) Dysthymia: G1: 1 (0) G2: 1 (0) Taking depression medications (%): NR Other co- morbidities, onset post-TBI, n (%resolved): PTSD: G1: 8 (38) G2: 9 (44) Other anxiety disorder: MDD and anxiety: G1: 7 (43) G2: 18 (39) Panic disorder: G1: 4 (75) G2: 7 (57) GAD: G1: 4 (0) G2: 4 (0) Phobias: G1: 4 (25) G2: 3 (33) Irritability: NR Aggression: NR Suicidality: NR
Author: Himanen et al., 2009 See Koponen et al., 2002 & Koponen et al., 2004; Koponen et al., 2005; Koponen et al., 2006 Country, Setting: Finland, tertiary care center Enrollment Period: February 1998 to April 1999 Design: Cross-sectional Time from injury, yrs ± SD: G1: 31.0 ± 3.6 G2: NA Length of follow up: NA Dep. Scale/Tool: BDI, SCAN | Inclusion criteria:; - A head trauma severe enough to cause TBI and neurological symptoms (including headache and nausea) lasting at least 1 week; - At least one of the following: LOC ≥ 1 min, PTA ≥ 30 min, neurological symptoms (excluding headache and nausea) during the first 3 days after injury, or neuroradiological findings suggesting TBI (e.g., skull fracture, intracerebral hemorrhage); Exclusion criteria:; - Neurological illness before TBI; - Clinical symptoms of a non-traumatic neurological illness that developed after TBI (excluding dementia); - Insufficient cooperation; - Unavailability of medical records | Group(s): G1: Participants with TBI G1a: TBI with depressive symptoms G1b: TBI without depressive symptoms G2: Neurologically healthy comparison group N screened: G1: 210 G2: NR N eligible: G1: 78 G2: NR N included: G1: 61 G1a: 32 G1b: 29 G2: 31 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI (%): NR Age, yrs ± SD: G1: 60.1 ± 10.6 G2: 61.1 ± 7.9 Age ≥16, N (%): 92 (100) | Depression: BDI: Short form version; score >5 indicates depressive symptoms SCAN: NR Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: MMSE: General cognitive impairment | Depressive symptoms, BDI, n (%): G1: 32 (52.5) G2: NR BDI mean ± SD: G1a: 9.6 ± 4.3 G1b: 1.0 ± 1.1 G2: 2.7 ± 3.1 Major depression, SCAN, n (%): G1: 6 (9.7) G2: NR Taking depression medications (%): NR Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: MMSE, mean ± SD: G1a: 25.6 ± 3.7 G1b: 27.7 ± 1.7 G2: 27.2 ± 2.3 G1 vs G2: p=0.026 (NS)
Author: Hoge et al., 2008 Country, Setting: US, other Enrollment Period: 2006 Design: Cross-sectional Time from injury: NR Length of follow up: NA Dep. Scale/Tool: PHQ-9 | Inclusion criteria:; - Soldiers from two U.S. Army combat infantry brigades returned from a yearlong deployment in Iraq were administered the questionnaire; Exclusion criteria:; - Incompletion of questionnaire; - Report of head injury without LOC or altered mental status; TBI Def: Mild TBI^*^: Concussion characterized by brief LOC or altered mental status. A soldier was considered to have had a mild traumatic brain injury if any of three questions – regarding “losing consciousness (knocked out),” “being dazed, confused, or ‘seeing stars,’” or “not remembering the injury” – elicited a positive response^*^ | Group(s): G1: TBI with LOC G2: TBI with altered mental status (AMS) G3: Other injury G4: No injury N screened: 4,618 N eligible: 2,525 N included: G1: 124 G2: 260 G3: 435 G4: 1,706 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: NR Age ≥16, n (%): 2,525 (100) Global injury severity: NR | Depression: PHQ: subjects had to meet DSM-IV criteria and report impairment in work, home, or interpersonal functioning at the “very difficult” level Other co- morbidities: PTSD: Subjects had to meet DSM-IV criteria (one intrusion symptom, three avoidance symptoms, and two hyperarousal symptoms) and had to have substantial distress, as measured by a total score of at least 50. Other anxiety disorder: NR Irritability: PHQ-9 Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Measures of Physical Health: Measured by the Patient Health Questionnaire 15- item somatic symptom severity scale (PHQ-15) | Depression: Major depression, n (%): G1: 27 (22.9) G2: 21 (8.4) G3: 28 (6.6) G4: 55 (3.3) Taking depression medication: NR Other co- morbidities: PTSD, n (%): G1: 54 (43.9) G2: 71 (27.3) PTSD Checklist score, mean ± SD: G1: 46.8 ±19.0 G2: 39.8 ±16.3 Other anxiety disorder: NR Substance use: NR Irritability: G1: 67 (56.8) G2: 118 (47.6) Aggression: NR Suicidality: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Patient Health Questionnaire score ≥15, n (%): G1: 30 (24.8) G2: 41 (16.1) Post-concussive memory problems, n (%): G1: 29/118 (24.6) G2: 41/253 (16.2) G3: 58/422 (13.7) G4: 124/1,680 (7.4)
Author: Holsinger et al., 2002 Country, Setting: US, other Enrollment Period: 1996 to 1997 Design: Cross-sectional Time from injury: Approximately 50 years Length of follow up: NA Dep. Scale/Tool: DSM-IV | Inclusion criteria:; - World War II US Navy or Marine Corps male veterans who were on active duty during 1944–1945 and hospitalized during their military service with a diagnosis of head injury, pneumonia, or laceration, puncture, or incision wounds; - Head trauma that was documented in the military medical records, occurred during military service, and produced LOC, PTA, or nondepressed skull fracture; Exclusion criteria:; - Head trauma that penetrated the duramater or resulted in significant cognitive impairment or neurological sequelae (likely to cause substantial limitation in ADLs) more than 3 months after trauma; - Dementia; - Head injury prior to enlistment | Group(s): G1: Veterans with recorded HI G2: Veterans with no recorded HI N screened: 5,444 N eligible: G1: 578 G2: 1,198 N included: G1: 528 G2: 1,198 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: G1: 73.2 ± 3.4 G2: 72.5 ± 3.8 Age ≥16, n (%): 1,718 (100) Global injury severity: NR Severity of TBI: NR | Depression: Major depression: 5 symptoms which included depressed mood or loss of interest/pleasure Minor depression: 2 symptoms, at least one of which had to be depressed mood or loss of interest/pleasure Lifetime depression: 2 wks of any of the following: Depressed, sad, or blue mood Loss of interest/pleasure Irritability Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: CAGE interview questionnaire ≥ 2 positive responses, indicative of possible alcohol abuse Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, lifetime, %: Major depression: G1: 18.5 G2: 13.4 Minor depression: G1: 7.1 G2: 5.3 Depression, life- time, HI severity, OR vs. no HI: Severe: 1.99 Moderate:1.40 Mild: 1.49 Major depression, current, %: G1: 11.2 G2: 8.5 Taking depression medications: NR Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use, n: G1: 409 G2: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR
Author: Homaifer et al., 2009 Country, Setting: US, tertiary care center Enrollment Period: NR Design: Cross-sectional Time from injury, years ± SD range: 23 ± 15 (1–51) Length of follow up: NA Dep. Scale/Tool: SCID, BDI-II | Inclusion criteria:; - Veterans receiving outpatient and inpatient services for treatment related to TBI and/or PTSD; Exclusion criteria:; - A history of neurologic disease other than TBI; - Sleep apnea; - Presence of the following psychiatric disorders: schizophrenia, psychosis, or bipolar I disorder; - Scores on the BDI-II that were more than 2 SDs higher than a historical mean of scores obtained by persons participating in this VA facility’s PTSD Residential Rehabilitation Program; - A Computerized Assessment of Response Bias performance of type III (very poor effort) or IV (extreme exaggeration or response bias); - Active substance abuse responses on the SCID-IV that suggested abuse in the 7 days prior to participation | Group(s): Participants with TBI N screened: 107 N eligible: 59 N included: 52 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI (%): 10 (19) with remote history of multiple TBIs Age, yrs ± SD (range): 51.7 ± 10.3 (23–74) Age ≥16, N (%): 52 (100) Global injury severity): NR Severity of TBI, n (%): Mild: 25 (48.1) Moderate: 9 (17.3) Severe: 18 (34.6) Mechanism/type of injury: NR Area of brain injured: NR | Depression: SCID: DSM-IV criteria for MDD BDI-II: Minimal: 0 to 13 Mild: 14 to 19 Moderate: 20 to 28 Severe: 29 to 63 Other co-morbidities: PTSD: SCID Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, SCID, n (%): 23 (44.2) BDI-II, mean ± SD (range): 25.0 ±14.6 (0–53) Taking depression medications (%): NR Other co- morbidities: PTSD, n (%): 18 (35) Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR
Author: Hoofien et al., 2001 Country, Setting: Israel, rehabilitation center Enrollment Period: NR Design: Cross-sectional Time from injury, yrs ± SD: 14.1 ± 5.5 Length of follow up: NA Dep. Scale/Tool: SCL-90-R | Inclusion criteria:; - Medically documented TBI occurring at least 5 yrs prior to the study; Exclusion criteria:; - Severe psychiatric problems; - Substance abuse; TBI Def: NR | Group(s): Patients with severe TBI N screened: 321 N eligible: 198 N included: 76 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: 24.9 ± 7.6 Age ≥16, n (%): 76 (100) Global injury severity: NR Severity of TBI, duration of coma, n (%): No coma: 5 (6.6) < 24 hrs: 9 (11.8) 1–7 days: 13 (17.1) 8–30 days: 26 (34.2) ≥ 30 days: 21 (27.6) Mechanism/type of injury, n (%): MVC: 48 (64) Combat: 19 (25) Work accident: 9 (11) | Depression: SCL-90-R > 95^th^ percentile of normative data Other co- morbidities: PTSD: NR Other anxiety disorder: SCL-90-R > 95^th^ percentile Irritability: NR Aggression: SCL-90-R > 95^th^ percentile Suicidality: NR Substance use: NR Other psychiatric diagnoses: SCL-90-R > 95^th^ percentile Health related QoL or functional status: GSI Acceptance of Disability Questionnaire Extended ADL: social activities, home activities, and independence in mobility subscales | Depression, %: 45.3 Taking depression medications: NR Other co- morbidities: PTSD: NR Other anxiety disorder: Anxiety, %: 43.8 Irritability: NR Aggression: Elevated SCL-90-R hostility score, %: 51.6 Suicidality: NR Substance use: NR Other psychiatric diagnoses, %: Psychoticism: 35.6 Obsessive- compulsive: 29.7 Phobic-ideation: 27.7 Paranoid ideation: 7.9 Interpersonal: 6.5 Health related QoL or functional status: GSI score, mean ± SD: 5.5 ± 0.7 Correlation between acceptance of disability and GSI and SCL-90-R subscales: GSI score: −0.7 Somatization: −0.7 Obsessive-compulsive: −0.6 Interpersonal sensitivity: −0.5
Author: Huang et al., 2005 Country, Setting: US, tertiary care center Enrollment Period: NR Design: Cross-sectional Time from injury: 1 year Length of follow up: NA Dep. Scale/Tool: SCID, ZDS | Inclusion criteria:; - TBI patients with closed head injuries; Exclusion criteria:; - Open head injuries; - Penetrating head injuries (e.g., stab wounds and missile wounds); - Non-traumatic brain injuries (e.g., stroke, malignancy and anoxic brain injuries); - Past or present disabling injuries in addition to brain trauma (e.g., patients with spinal cord and brain injuries); - Pre-existing or current DSM-IV Axis I and II psychiatric disorders as determined by a psychiatrist at the institution; TBI Def: Mild: GCS score of 13 to 15 Moderate: GCS score of 9 to 12 Severe: GCS score of 3 to 8 | Group(s): G1: Patients with mild TBI G2: Patients with moderate TBI G3: Patients with severe TBI N screened: 70 N eligible: 61 N included: G1: 22 G2: 20 G3: 17 N at conclusion: NA Depression: Prior to injury: None (see exclusion criteria) At time of injury: None (see exclusion criteria) Other preexisting psychiatric conditions: None (see exclusion criteria) N with prior TBI: NR Age, yrs ± SD: G1: 45.5 ± 8.2 G2: 45.9 ± 7.7 G3: 41.7 ± 6.7 Age ≥16, n (%): 59 (100) Global injury severity: NR | Depression: SCID: DSM-IV criteria ZDS cutoff: 55 Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, SCID, n (%): G1: 0 G2: 1 (5) G3: 7 (41) MDD, ZDS, n (%): G1: 0 G2: 0 G3: 10 (59) ZDS score, mean ± SD: G1: 24.9 ± 2.1 G2: 42.8 ± 3.5 G3: 54.7 ± 4.8 Taking depression medications: NR Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR
Author: Jorge, Robinson, Arndt, Forrester et al., 1993 See Federoff et al., 1992 & Jorge, Robinson, and Arndt, 1993 & Jorge, Robinson, Arndt, Starkstein et al., 1993 Country, Setting: US, trauma center Enrollment Period: NR Design: Prospective cohort Time from injury: NA Length of follow up: 12 months Dep. Scale/Tool:, DSM-III-R, HAM-D, PSE | Inclusion criteria:; - Shock trauma admissions with acute closed head injury; Exclusion criteria:; - Penetrating head injuries or associated spinal cord injury; - Multiple system involvement such as fractures which would influence physical recovery or produce significant secondary brain damage as a result of hypovolemic shock or severe hypoxia (abdominal hemorrhages or lung collapse); - Decreased level of consciousness (drowsy, stuporous, or comatose) or delirium; - Aphasic disorders (unable to follow a two-stage command) that interfered with comprehension of questions; TBI Def: Injury that requires medical treatment Mild TBI: GCS 12 to 15 | Group(s): G1: Patients with acute-onset major depression G2: Patients with delayed-onset major depression G3: Nondepressed patients N screened: NR N eligible: NR N included: 66 N at conclusion: G1: 17 G2: 11 G3: 32 Depression, n: Prior to injury: 0 At time of injury: 0 Other preexisting psychiatric conditions, n (%): History of psychiatric disorder: G1: 12 (70.6) G2: 9 (81.8) G3: 6 (19.3) N with prior TBI: NR Age, yrs ± SD: G1: 26.8 ± 5.8 G2: 28.9 ± 6.4 G3: 29.5 ± 11.7 Age ≥16: NR Global injury severity: NR | Depression: Patient self-report of depressed mood; structured initial psychiatric evaluation with assessment for DSM-III criteria for depression; Hamilton Depression Rating Scale (HAM- D); Present State Examination (PSE) Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Johns Hopkins Functioning Inventory (JHFI) Social Functioning Exam (SFE) Social Ties Checklist (STC) | Depression, n (%): Initial evaluation: MDD: 17/66 (25.8) Minor depression: 2/66 (3.0) Delayed onset: MDD: 11/66 (16.7) Minor depression: 4/66 (6.1) HAM-D score, mean ± SD: G1: 13.8 ± 3.2 G2: 11.0 ± 1.3 G3: 5.5 ± 2.4 Taking depression medications, n: ≥ 2 Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: JHFI score, mean ± SD: G1: 2.2 ± 3.3 G2: 0.4 ± 0.8 G3: 1.0 ± 0.9 G1/G2: P < 0.05 STC score, mean ± SD: G1: 4.2 ± 1.2 G2: 4.3 ± 1.6 G3: 3.6 ± 1.1 G1/G3: P < 0.05 G2/G3: P < 0.05
Author: Jorge et al., 2004 See Tateno et al., 2003; Tateno et al., 2004 Country, Setting: US, tertiary care centers Enrollment Period: NR Design: Prospective cohort Time from injury: NR Length of follow up: 12 months Dep. Scale/Tool: SCID | Inclusion criteria: See exclusion criteria Exclusion criteria:; - Penetrating head injuries; - Clinical or radiological findings suggesting spinal cord injury; - Patients with severe comprehension deficits (i.e., those who were unable to complete part II of the Token Test) that precluded a thorough neuropsychiatric evaluation; TBI Def: Mild TBI: GCS score between 13 and 15 Moderate TBI: GCS score between 9 and 12, or GCS score of 12 to 15 with intracranial surgical procedures or with focal lesions greater than 15 mL Severe TBI: GCS score between 3 and 8 | Group(s): G1: Patients with TBI G2: Trauma patients without central nervous system damage N screened: NR N eligible: NR N included: G1: 91 G2: 27 N at conclusion: G1: 74 G2: 27 Depression, n (%): Prior to injury: G1: 18 (19.8) G2: 4 (14.8) At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: G1: 36.4 ± 15.7 G2: 35.7 ± 14.1 Age ≥16, n (%): NR Global injury severity, AIS score, mean: 16.8 Severity of TBI, %: Mild: 44.3 Moderate: 32.5 Severe: 23.2 | Depression: SCID: DSM-IV criteria Other co- morbidities: PTSD: see below Other anxiety disorder: SCID: PTSD, GAD, panic Irritability: NR Aggression: Overt Aggression Scale (OAS) Suicidality: NR Substance use: NR Other psychiatric diagnoses: Health related QoL or functional status: FIM RAVLT WCST Trail Making Test Stroop Color-Word Interference Test Multilingual Asphasia Examination | Depression, n (%): G1: 30 (33) Initial evaluation: 15/30 (50) 3 months: 9/30 (30) 6 months: 6/30 (20) Taking depression medications, n (%): 8 (33) Other co- morbidities, %: PTSD: See below Other anxiety Disorder (includes PTSD): 43.2 Irritability: NR Aggression: 36.5 Suicidality: NR Substance use: Concurrent alcohol abuse, patients with TBI and major depression: 6.7 Concurrent other drug abuse, patients with TBI and major depression: 6.7 Other psychiatric diagnoses: NR Health related QoL or functional status: FIM score, mean: 62.7 RAVLT score, mean ± SD: 8.3 ± 2.8 WCST Perseverative score, mean ± SD: 13.9 ± 11.1
Author: Jorge, Robinson, Starkstein, and Arndt, 1994 See Federoff et al., 1992 & Jorge, Robinson, and Arndt, 1993 & Jorge, Robinson, Arndt, Starkstein et al., 1993 Country, Setting: US, trauma center Enrollment Period: NR Design: Prospective cohort Time from injury, days, median (IQR): 31 (32) Length of follow up: 12 months Dep. Scale/Tool: DSM-III-R, HAM-D, PSE | Inclusion criteria:; - Acute closed head injury; Exclusion criteria:; - Penetrating head injuries or associated spinal cord injury; - Multiple system involvement such as fractures which would influence physical recovery or produce significant secondary brain damage as a result of hypovolemic shock or severe hypoxia (abdominal hemorrhages or lung collapse); - Decreased level of consciousness (drowsy, stuporous, or comatose) or delirium; - Aphasic disorders (unable to follow a two-stage command) that interfered with comprehension of questions | Group(s): G1: Patients with major depression G2: Patients with major depression and anxiety G3: Nondepressed patients N screened: NR N eligible: NR N included: 66 N at conclusion: G1: 10 G2: 7 G3: 47 Depression, n: Prior to injury: 0 At time of injury: 0 Other preexisting psychiatric conditions, n (%): Psychiatric disorder: G1: 2 (20.0) G2: 2 (28.6) G3: 11 (23.4) Personal history of alcohol abuse, %: G1: 40 G2: 14 G3: 17 N with prior TBI: NR Age, yrs ± SD: G1: 29.4 ± 6.2 G2: 25.0 ± 5.0 G3: 30.1 ± 10.8 Age ≥16: NR | Depression: Patient self-report of depressed mood; structured initial psychiatric evaluation with assessment for DSM-III criteria for depression; Hamilton Depression Rating Scale (HAMD-D); Present State Examination (PSE) Other co- morbidities: PTSD: NR Other anxiety disorder: DSM-III R criteria for Anxiety & depression PSE for mood & anxiety disorders Irritability: NR Aggression: NR Suicidality: NR Substance use: Other psychiatric diagnoses: Health related QoL or functional status: Johns Hopkins Functioning Inventory (JHFI) | Depression, n (%): MDD: 17/66 (25.8) HAM-D score, mean ± SD: G1: 12.6 ± 2.9 G2: 15.4 ± 2.9 G3: 6.7 ± 2.6 Taking depression medications, n: Benzodiazepines: G1+G2: 16 Antidepressants: G1+G2: 0 Other co- morbidities: PTSD: NR Other anxiety disorder: PSE score, mean ± SD: G1: 18.1 ± 3.7 G2: 21.8 ±4.2 G3: 7.2 ± 4.6 Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status, JHFI score, mean ± SD: G1: 2.1 ± 2.0 G2: 0.9 ± 1.1 G3: 1.5 ± 2.8
Author: Jorge, Robinson, Starkstein, and Arndt, 1994 See Federoff et al., 1992 & Jorge, Robinson, and Arndt, 1993 & Jorge, Robinson, Arndt, Starkstein et al., 1993 Country, Setting: US, trauma center Enrollment Period: NR Design: Prospective cohort Time from injury, n: 3 months: 52 6 months: 43 12 months: 43 Length of follow up: 12 months Dep. Scale/Tool: Modified version of the PSE using DSM- III-R criteria | Inclusion criteria:; - Acute closed head injury; Exclusion criteria:; - Penetrating head injuries or associated spinal cord injury; - Multiple system involvement such as fractures which would influence physical recovery or produce significant secondary brain damage as a result of hypovolemic shock or severe hypoxia (abdominal hemorrhages or lung collapse); - Decreased level of consciousness (drowsy, stuporous, or comatose) or delirium; - Aphasic disorders (unable to follow a two-stage command) that interfered with comprehension of questions; TBI Def: Injury that requires medical treatment Mild TBI: GCS 12 to 15 | Group(s): Patients with TBI N screened: NR N eligible: NR N included: 66 N at conclusion: 52^*^ Depression, n: Prior to injury: 0 At time of injury: 0 Other preexisting psychiatric conditions: Unable to determine N with prior TBI: NR Age, yrs ± SD: NR Age ≥16: NR Global injury severity: NR Severity of TBI, %: Severe: 17 Moderate: 68 Mild: 15 GCS score, median (IQR): 10 (6) Mechanism/type of injury: MVA: “Most” Area of brain injured: Reported but unable to determine from data presented | Depression: DSM-III-R criteria Other co- morbidities: PTSD:NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Johns Hopkins Functioning Inventory (JHFI) Social Functioning Exam (SFE) Social Ties Checklist (STC) | Depression, n (%): MDD: 13 (25) Minor depression: 1 (2) Taking depression medications: NR Other co- morbidities, n: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: Bipolar disorder: 1/52 Secondary mania (elevated mood): 5/52 Health related QoL or functional status: Poor psychosocial outcome, n: Long-lasting MDD: 4/6 No affective disorder: 3/19 P = 0.03 Poor ADL’s outcome, n: Long-lasting MDD: 2/4 No affective disorder: 0/10 P = 0.03
Author: Kant et al., 1998 Country, Setting: US, tertiary care center Enrollment Period: NR Design: Cross-sectional Time from injury: NR Length of follow up: NA Dep. Scale/Tool: DSM-III-R, BDI | Inclusion criteria:; - Closed head injury (CHI); Exclusion criteria: See inclusion criteria TBI Def: Mild TBI: GCS 13 to 15 and/or LOC < 20 min Moderate TBI: GCS 9 to 12 and/or LOC > 20 min but < 24 hrs Severe TBI: GCS < 8 and/or LOC > 24 hrs | Group(s): G1: CHI with apathy and no depression G2: CHI with depression and no apathy G3: CHI with apathy and depression G4: CHI with neither apathy nor depression N screened: NR N eligible: NR N included: G1: 9 G2: 9 G3: 50 G4:15 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions, n (%): History of psychiatric treatment: 10 (12) N with prior TBI (%): 8 (9.6) Age, yrs ± SD: G1: 29.0 ± 11.9 G2: 41.8 ± 12.9 G3: 38.1 ± 11.5 G4: 42.1 ± 12.9 Age ≥16: NR Global injury severity: NR | Depression: DSM-III-R criteria BDI > 11 Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: Apathy Evaluation Scale Health related QoL or functional status: NR | Depression, n (%): 59 (71.1) BDI score, mean ± SD: G1: 7.3 ± 2.5 G2: 18.0 ± 5.3 G3: 23.5 ± 8.6 G4: 6.2 ± 2.4 Taking depression medications: NR Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: Apathy, AES, n (%):59 (71.1) Health related QoL or functional status: NR
Author: Kashluba et al., 2006 Country, Setting: Canada, tertiary care centers Enrollment Period: NR Design: Prospective cohort Time from injury days ± SD: G1: 12.1 ± 5.8 Length of follow up: 3 months Dep. Scale/Tool: ICD-10 | Inclusion criteria: See exclusion criteria Exclusion criteria:; - History of inpatient treatment for any psychiatric disorder; - Diagnosis of mental retardation; - Inability to read fluently in English based on self- report; - History of TBI more severe than MTBI at any point in their life; - MTBI within 1 year prior to participation in the MTBI study; - Any ongoing central nervous system disorder; - Concurrent pregnancy; TBI Def: According to ACRM criteria | Group(s): G1: Participants with TBI G2: Uninjured participants matched by age, sex, and years of education N screened: NR N eligible: NR N included: G1: 110 G2: 118 N at conclusion: G1: 110 G2: 118 Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: G1: 33.1 ± 12.0 G2: 30.4 ± 11.7 Age ≥16, n (%): 228 (100) Global injury severity: NR Severity of TBI: NR Mechanism/type of injury: NR Area of brain injured: NR | Depression: Problem Checklist from the New York Head Injury Family Interview ICD-10 definition for PCS Other co- morbidities: PTSD: NR Other anxiety disorder: Problem Checklist from the New York Head Injury Family Interview ICD-10 definition for PCS Irritability: ICD-10 definition for PCS Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: PCS symptoms using ICD-10 definition for PCS: fatiguing quickly, dizziness/vertigo, poor concentration, being forgetful, headaches, sleep disturbances, irritability | Depression, 1 month, %: G1: 40 G2: 33 G1/G2: P = NS Depression, 3 months, %: G1: 39 G2: 37 G1/G2: P = NS Taking depression medications: NR Other co- morbidities, %: PTSD: NR Other anxiety disorder: Anxiety/tension,1 month: G1: 63 G2: 60 G1/G2: P = NS Anxiety/tension, 3 months: G1: 51 G2: 58 G1/G2: P = NS Irritability, 1 month: G1: 61 G2: 47 G1/G2: P < 0.05 Irritability, 3 months: G1: 56 G2: 47 G1/G2: P = NS Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR
Author: Keiski et al., 2007 Country, Setting: Canada, other Enrollment Period: NR Design: Cross-sectional Time from injury, months ± SD: 17.8 ± 16.8 Length of follow up: NA Dep. Scale/Tool: PAI | Inclusion criteria:; - 18 to 49 years of age; - At least a mild TBI; Exclusion criteria:; - Injury received prior to age 15 years; - Diagnosis of a condition unrelated to the brain injury (e.g., schizophrenia, developmental disability) that would grossly affect subject performance; - Any deficits preventing a subject from completing a substantial portion of a comprehensive neuropsychological evaluation (e.g., aphasia, sensory impairment); TBI Def: Mild TBI: Head injury resulting in any period of loss of consciousness, any loss of memory (whether retrograde or anterograde), any alteration in mental state, or focal neurological deficits (based on ACRM criteria) | Group(s): Patients with TBI N screened: NR N eligible: NR N included: 53^*^ N at conclusion: NA Depression status prior to TBI: NR N with prior TBI: NR Age, yrs ± SD: 33.7 ± 10.1 Age ≥16, n (%): 53 (100)^*^ Global injury severity: NR Severity of TBI, n (%): Moderate: 16 (30.1) Mild: 37 (69.8) Mechanism/type of injury: Most were MVA Area of brain injured: NR Concomitant injuries: NR Baseline depression status: NR | Depression: PAI > 70 Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, n (%): 24/43 (55.8)^*^ Taking depression medications: NR Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR
Author: Kennedy et al., 2005 Country, Setting: US, other Enrollment Period: NR Design: Cross-sectional Time from injury, mos ± SD: 76 ± 94 Length of follow up: NA Dep. Scale/Tool: SCID | Inclusion criteria:; - At least 18 yrs old; - At least 3 months postinjury; Exclusion criteria: See inclusion criteria TBI Def: Damage to brain tissue caused by an external mechanical force, as evidenced by LOC due to head trauma, PTA, skull fracture, or objective neurological findings Mild TBI: GCS score of 13 to 15 Moderate TBI: GCS score of 9 to 12 Severe TBI: GCS score of 3 to 8 | Group(s): Participants with TBI N screened: NR N eligible: NR N included: 78 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD (range): 38.0 ± 12.2 (18–69) Age ≥16, n (%): 78 (100) Global injury severity: NR Severity of TBI, GCS score, %:^*^ Severe: 43 Moderate: 12 Mild: 45 GCS score, mean ± SD: 9.3 ± 4.8 Mechanism/type of injury, %: MVC: 77 Assault: 12 Area of brain injured: NR | Depression: SCID: DSM-IV criteria for MDD or depression due to general medical condition (GMC) Other co- morbidities: PTSD: Other anxiety disorder: Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, SCID-I, %: Total depressive disorder: 50 MDD: 14 Current MDD with/without a GMC at evaluation, %: 30 Taking depression medications: NR Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR
Author: Kersel et al., 2001 See Marsh and Kersel, 2006 Country, Setting: New Zealand, tertiary care center Enrollment Period: April 1993 to August 1996 Design: Prospective cohort Time from injury, days ± SD (range): 201 ± 23 (153–277); 387 ± 33 (345–497) Length of follow up: 12 months Dep. Scale/Tool: BDI short form, HIBS | Inclusion criteria:; - 16 to 60 yrs old; - Consent obtained from next-of-kin to participate in the study; - Severe TBI as indicated by a GCS score of < 9 obtained prior to intubation and within 24 hours of the injury; - The patient was required to be ventilated on clinical grounds for > 24 hours, where the ventilation was, at least in part, required for the treatment of the TBI; - English-speaking; Exclusion criteria:; - Previous psychiatric history; - Prior significant TBI requiring hospitalization; TBI Def: Severe TBI: GCS score of < 9 | Group(s): Patients with TBI N screened: 123 N eligible: 123 N included: 123 N at conclusion: 58 Depression: Prior to injury: None, see inclusion criteria At time of injury: None, see inclusion criteria Other preexisting psychiatric conditions: None, see inclusion criteria N with prior TBI: NR Age, yrs ± SD: 28.0 ± 11.0 Age ≥16, n (%): 123 (100) Global injury severity: NR Severity of TBI, %: Severe: 100 Mechanism/type of injury, n (%): Road traffic crash: 49 (75) Fall: 7 (11) Assault: 5 (8) Other causes (including sports injuries): 4 (6) | Depression: BDI short form: NR HIBS, patient version: NR Other co- morbidities: PTSD: NR Other anxiety disorder: HIBS Irritability: HIBS Aggression: HIBS Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: HIBS describes other characteristics in addition to depression and anxiety Glasgow outcome scale (GOS): Severely disabled, moderately disabled & good recovery | Depression (BDI), 6 mos, n (%): Severe depression: 9 (16) Mild depression: 5 (9) Total clinically depressed: 14 (24) BDI score, 6 mos, mean ± SD: 3.5 ± 4.4 Depression (HIBS), 6 mos, n (%): 25 (42) Depression (BDI), 12 mos, n (%): Severe depression: 6 (10)^*^ Mild depression: 8 (14)^*^ Total clinically depressed: 14 (24) BDI score, 12 mos, mean ± SD: 3.6 ± 4.6. Depression (HIBS), 12 mos, n (%): 28 (47) Taking depression medications: NR Other co- morbidities, n (%): PTSD: NR Other anxiety disorder: 6 mos: 23 (39) 12 mos: 26 (44) Irritability: 6 mos: 29 (49) 12 mos: 26 (44) Aggression: 6 mos: 8 (14) 12 mos: 9 (15)
Author: Kinsella et al., 1988 Country, Setting: Australia, rehabilitation centers Enrollment Period: NR Design: Cross-sectional Time from injury mos, n (%): G1: <6: 12 (30.7) 7–12: 11 (28.2) 13–18: 8 (20.5) 19–24: 8 (20.5) G2: NA Length of follow up: NA Dep. Scale/Tool: Leeds Scales for Anxiety and Depression, VAS-D | Inclusion criteria:; - 16 to 60 yrs old; - Within 2 yrs of injury; - “Close others” had frequent and personal contact with the head injured patients over a variety of situations during the last 2–3 months; Exclusion criteria:; - Premorbid history of serious brain impairment; TBI Def: Severe CHI: Brain damage without skull penetration, and had been unconscious and incurred a PTA of greater than 24 hrs | Group(s): G1: Patients with CHI G2: “Close others” to CHI patients N screened: NR N eligible: NR N included: G1: 39 G2: 35 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, mean: G1: 27.8 G2: NR Age ≥16, n (%): G1: 39 (100) G2: NR Global injury severity (ISS, RTS, etc.): NR Severity of TBI, n (%): Duration of LOC: <24 hours: 3 (7.7) 1–7 days: 9 (23.1) 1–4 weeks: 14 (35.9) >4 weeks: 10 (25.6) Unknown: 3 (7.7) Duration of PTA: 1–7 days: 1 (2.6) 1–4 weeks: 9 (23.1) >4 weeks: 29 (74.4) | Depression: Leeds Scale for Depression: 15-items that describe common symptoms of depression and cut- off points used were the recommended 6/7 Visual Analogue Scale for Depression: The distance (measured in mm), from the non- depressed ends of the scale to where the subjects mark the scale indicates the severity of depression Other co- morbidities: PTSD: NR Other anxiety disorder: Leeds Scale for Anxiety, Visual Analogue Scale for Anxiety, Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: GHQ: | Depression, n (%)^*^: Leeds Scale for Depression: G1: 13 (33.3) VAS-D: G1/G2: ρ= 0.5090 Taking depression medications: NR Other co- morbidities, n (%)^*^: PTSD: NR Other anxiety disorder: Leeds: G1: 10 (25.6) VAS-A: G1/G2: ρ= 0.5265 Irritability :NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: GHQ minor non- psychotic psychiatric disorders: G1: 23 (59.0) Health related QoL or functional status: Physical Disability: A high score on the GHQ was best predicted by physical handicap (accounting for 12% of the variance)
Author: Koponen et al., 2006 See Koponen et al., 2002 & Koponen et al., 2004; Koponen et al., 2005; Himanen et al., 2009 Country, Setting: Finland, tertiary care center Enrollment Period: January 1998 to April 1999 Design: Cross-sectional Time from injury, yrs ± SD: 31.5 ± 4.5 Length of follow up: NA Dep. Scale/Tool: SCID | Inclusion criteria:; - A head trauma severe enough to cause TBI and neurological symptoms (including headache and nausea) lasting at least 1 week; - At least one of the following: LOC ≥1 min, PTA ≥30 min, neurological symptoms (excluding headache and nausea) during the first 3 days after injury, or neuroradiological findings suggesting TBI (e.g., skull fracture, intracerebral hemorrhage); Exclusion criteria:; - Neurological illness before TBI; - Clinical symptoms of a non-traumatic neurological illness that developed after TBI (excluding dementia); - Insufficient cooperation; - Unavailability of medical records | Group(s): Patients with TBI N screened: 210 N eligible: 118 N included: 58 N at conclusion: NA Depression: Prior to injury: 0 At time of injury: 0 Other preexisting psychiatric conditions, n (%): Anxiety disorders: 6 (10.3) Schizoaffective disorder: 1 (1.7) N with prior TBI: NR Age, yrs ± SD: 60.7 ± 10.2 Age ≥16, n (%): 58 (100) Global injury severity: NR Severity of TBI, n (%): Mild: 15 (25.9) Moderate: 15 (25.9) Severe: 9 (15.5) Very severe: 19 (32.8) | Depression: SCID: DSM-IV criteria Other co- morbidities: PTSD: NR Other anxiety disorder: DSM-IV criteria Irritability: NR Aggression: NR Suicidality: NR Substance use: DSM-IV criteria Other psychiatric diagnoses: DSM-IV criteria Health related QoL or functional status: NR | Depression: Major depression, n (%): Total: 14 (24.1) Patients with contusions: 3/17 (17.6) Patients without contusions: 11/41 (26.8) P = 0.52 Taking depression medications: NR Other co- morbidities, n (%): PTSD: NR Other anxiety disorder: Anxiety disorders: 10 (17.2) Irritability: NR Aggression: NR Suicidality: NR Substance use: Alcohol abuse or dependence: 7 (12.1) Other psychiatric diagnoses: Any Axis I: 27 (46.6) Delusional: 3 (5.2) Psychotic: 1 (1.7) Bipolar II: 1 (1.7) Dissociative amnesia: 1 (1.7) Dementia: 3 (5.2) Any Axis II disorder, n (%): 17 (29.3) Health related QoL or functional status: NR
Author: Koponen et al., 2005 See Koponen et al., 2002 & Koponen et al., 2004; Koponen et al., 2006; Himanen et al., 2009 Country, Setting: Finland, tertiary care center Enrollment Period: NR Design: Cross-sectional Time from injury, median yrs (range): 29.7 (26–47) Length of follow up: NA Dep. Scale/Tool: SCID, BDI | Inclusion criteria:; - A head trauma severe enough to cause TBI and neurological symptoms (including headache and nausea) lasting at least 1 week; - At least one of the following: LOC ≥1 min, PTA ≥30 min, neurological symptoms (excluding headache and nausea) during the first 3 days after injury, or neuroradiological findings suggesting TBI (e.g., skull fracture, intracerebral hemorrhage); Exclusion criteria:; - Neurological illness before TBI; - Clinical symptoms of a non-traumatic neurological illness that developed after TBI (excluding dementia); - Insufficient cooperation; - Unavailability of medical records | Group(s): G1: Patients referred for neuropsychological evaluation due to a recent TBI or with significant disability after an earlier TBI G2: Participants matched for gender, age, and severity of depression N screened: 210 N eligible: 118 N included: G1: 54 G2: 54 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, median (range): G1: 58.8 (44–80) G2: 59.0 (44–64) Age ≥16, n (%): 108 (100) Global injury severity: NR | Depression: SCID: DSM-IV criteria BDI-13: ≥16: Severe 8–15: Moderate 5–7: Mild 0–4: None/minimal Other co- morbidities: PTSD: NR Other anxiety disorder: SCID Irritability: NR Aggression: NR Suicidality: NR Substance use: SCID Other psychiatric diagnoses: SCID Health related QoL or functional status: NR | Depression, SCID, n (%): MDD: G1: 3/54 (5.6) Depression, BDI-13, n (%): Severe: G1: 3/52 (5.8) G2: 3/54 (5.6) Moderate: G1: 14/52 (26.9) G2: 14/54 (25.9) Mild: G1: 8/52 (15.4) G2: 6/54 (14.8) None/minimal: G1: 27/52 (51.9) G2: 29/54 (53.7) BDI-13 score, median (range): G1: 3.5 (0–26) G2: 4.0 (0–19) Taking depression medications (%): NR Other co- morbidities, n (%): PTSD: NR Other anxiety Disorder: G1: 10/54 (18.5) Irritability: NR Aggression: NR Suicidality: NR Substance use: Alcohol abuse/dependence: G1: 4/54 (7.4) Other psychiatric diagnoses: Alexithymia: G1: 17/54 (31.5) G2: 8/54 (14.8)
Author: Koponen et al., 2002^*^ Koponen et al., 2004^ See Koponen et al., 2005; Koponen et al., 2006; Himanen et al., 2009 Country, Setting: Finland, tertiary center Enrollment Period: NR Design: Cross-sectional Time from injury, yrs ± SD: 31.4 ± 4.4 Length of follow up: NA Dep. Scale/Tool: SCAN | Inclusion criteria:; - Head trauma severe enough to cause TBI and neurological symptoms (including headache and nausea) lasting at least 1 week; - At least one of the following: LOC ≥1 minute, PTA ≥t 30 minutes, neurological symptoms (excluding headache and nausea) during the first 3 days after the injury, or neuroradiological findings suggesting TBI (e.g., skull fracture, intracerebral hemorrhage); Exclusion criteria:; - Neurological illness before the brain injury; - Clinical symptoms of a nontraumatic neurological illness that developed after the TBI (excluding dementia); - Insufficient cooperation; - Unavailability of medical records | Group(s): G1: Patients with TBI and positive for the APOE-ɛ4 allele G2: Patients with TBI and negative for the APOE-ɛ4 allele N screened: NR N eligible: 210 N included: Total^*^: 60 G1^: 19 G2^: 41 N at conclusion: Total^*^: 60 G1^: 19 G2^: 41 Depression, n: Prior to injury: 0 At time of injury: NR Other preexisting psychiatric conditions, n (%): Schizoaffective disorder: 1 (1.7) Delusional disorder: 0 Psychotic disorder not otherwise specified: 0 Bipolar II disorder: 0 Panic disorder: 0 Specific phobia: 5 (8.3) Social phobia: 3 (5) Generalized anxiety disorder: 0 Dissociative amnesia: 0 | Depression: SCAN: DSM-IV criteria Other co- morbidities: PTSD: NR Other anxiety disorder: SCID: DSM-III-R criteria Irritability: NR Aggression: NR Suicidality: NR Substance use: SCID: DSM-III-R criteria Other psychiatric conditions: SCID: DSM-III-R criteria^*^ Health related QoL or functional status: NR | Depression, ever, n: Total: 16 G1: 6 G2: 10 Depression, onset post-TBI, n (%): < 1 year: 6 (10) 1–10 years: 0 > 10 years: 10 (16.7) Depression, current, n (%): 6 (10) Taking depression medications: NR Other co- morbidities: PTSD: NR Other anxiety disorder: Anxiety disorder, n:^ Total: 11 G1: 3 G2: 8 Generalized anxiety disorder, onset post- TBI, n (%):^*^ < 1 year: 0 1–10 years: 1 (1.7) > 10 years: 0 Generalized anxiety disorder, current: 1 (1.7) Substance use: Alcohol abuse or dependence, n:^ Total: 7 G1: 2 G2: 5 Alcohol dependence, onset post-TBI, n (%):^*^ < 1 year: 1 (1.7) 1–10 years: 0 > 10 years: 0
Author: Kreuter, Sullivan et al., 1998 Kreuter, Dahllof et al., 1998^ Country, Setting: Sweden, tertiary care center Enrollment Period: G1: 1971 to 1990 G2: November 1982 to July 1991 G3: NR Design: Cross-sectional Time from injury, median yrs (range): G1: 9 (1–20) G2: 5 (1–9) G3: NA Length of follow up: NA Dep. Scale/Tool: HADS | Inclusion criteria:; - 16 to 60 yrs old at time of injury (G1); - Over 18 yrs old at time of study; Exclusion criteria:; - Older than 70 at time of study, commotio cerebri injury, severe injuries precluding participation, or heavy alcohol abuse (G1); - Psychiatric illness (G2); TBI Def: NR | Group(s): G1: Patients with TBI G2: Patients with spinal cord injuries G3: Healthy participants N screened: G1: 152 G2: 252 G3: 334 N eligible: G1: 116 G2: 167 G3: 334 N included: G1: 92 G2: 167 G3: 264 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: G1: 40.5 ± 11.1 G2: 38.9 ± 15.7 G3: 36.9 ± 15.4 Age ≥16, n (%): 523 (100) Global injury severity: Patients required an operation due to their intracranial injuries, %:^ G1: 45 | Depression: Six items from the HADS scale Other co- morbidities: PTSD: NR Other anxiety disorder: HADS Anxiety Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Global quality of life: recorded on a visual analogue scale (VAS) and endpoints were labeled ‘very low’ and ‘very high’. For G2 and G3 participants, a 0–100 scale was applied while the TBI patients were examined with the aid of an earlier scale version linearly transformed to match the current scale. The higher score the better. Functional limitations: SIP GOS: Severe disability Moderate disability Good Recovery | Depression, %:^ Morbid depression: G1: 10 Borderline depression: G1: 16 HADS depression score, mean ± SD: G1^: 5.4 ± 4.3 G1: 4.7 ± 4.0 G2: 4.7 ± 3.8 G3: 2.7 ± 2.6 G1/G2: P = NS G1/G3: P < 0.001 G2/G3: P < 0.001 Taking depression medications, %: G1^: 10 G2: NR G3: NR Other co- morbidities: PTSD: NR Other anxiety disorder:^ Morbid anxiety: G1: 12 Borderline anxiety: G1: 18 HADS anxiety score, mean ± SD: G1^: 5.8 ± 4.9 G2: NR G3: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR
Author: Kreutzer et al., 2001 Country, Setting: US, trauma center Enrollment Period: NR Design: Cross-sectional Time from injury, yrs ± SD: 2.5 ± 3.5 Length of follow up: NR Dep. Scale/Tool: SCID, NFI | Inclusion criteria:; - Patients with brain injury referred for outpatient assessment; Exclusion criteria: See inclusion criteria TBI Def: NR | Group(s): Outpatients with TBI N screened: NR N eligible: NR N included: 722 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: 36.0 ± 12.1 Age ≥16, n (%): 722 (100) Global injury severity: NR Severity of TBI, LOC, days ± SD (range): 10.0 ± 27.6 (0–210) Mechanism/type of injury, %: MVA: 76 Assault: 8 Falls: 7 Area of brain injured: NR Concomitant injuries: NR | Depression: SCID: DSM-IV criteria NFI scales grouped with DSM-IV symptom domains to examine the value of the NFI as a diagnostic instrument Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: DSM-IV Aggression: NR Suicidality: NFI Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, %: MDD: 42 Taking depression medications: NR Other co- morbidities, %: PTSD: NR Other anxiety disorder: NR Irritability: Jumpy or irritable: 25 Aggression: NR Suicidality: Threaten to hurt themselves: Sometimes: 13 Often or always: 3 Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR
Author: Levin et al., 2005 See McCauley et al., 2005 Country, Setting: US, trauma center Enrollment Period: August 2001 to April 2003 Design: Prospective cohort Time from injury: NR Length of follow up: 12 weeks Dep. Scale/Tool: SCID, CES-D | Inclusion criteria:; - Arrival to the hospital within 24 hours of injury; - Blood alcohol level less than 200 mg/dL; - Age 16 years and older; - Fluent in English or Spanish; - Residing in the hospital catchment area (Harris County, Texas); - Diagnosis of non- penetrating TBI; - Lowest post- resuscitation GCS > 8; - CT scan of the brain performed within 24 hours of arrival; Exclusion criteria:; - Undocumented alien, incarcerated, homeless, or on active military service; - Spinal cord injury; - Previous TBI requiring hospitalization | Group(s): Patients with TBI N screened: NR N eligible: NR N included: 239 N at conclusion: 129 Depression: Prior to injury: None (see exclusion criteria) At time of injury: None (see exclusion criteria) Other preexisting psychiatric conditions: None (see exclusion criteria) N with prior TBI: NR Age at conclusion, yrs ± SD: 31.5 ± 12.8 Age ≥16, n (%): 129 (100) Global injury severity, ISS score, mean ± SD: 3.1 ± 4.1 GCS score, mean ± SD: 14.8 ± 0.5 Mechanism/type of injury, n (%): Car accident: 87 (67.4) Assault: 27 (20.9) Fall/jump: 10 (7.8) Other: 5 (3.9) | Depression: SCID: DSM-IV criteria Predictors of MDE at 3 months determined by Odds Ratio (OR) Predictive model includes CES-D score, older age, and CT scan results^*^ Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, 3 months, n (%): MDE: 15 (11.6) MDE with abnormal CT scan (vs. no CT abnormality), OR (95% CI): 7.7 (1.4, 43.5) Taking depression medications: NR Other co- morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR Multivariate model predictors, OR (95% CI): Older age at injury: 1.1 (1.0, 1.1) Abnormal CT result: 7.7 (1.4, 43.5) Higher one-week CES-D scores: 1.1 (1.0, 1.2)
Author: Levin et al., 2001 See McCauley et al., 2001 Country, Setting: US, trauma center Enrollment Period: NR Design: Cross-sectional Time from injury, mos ± SD : G1: 3.20 ± 1.45 G2: 3.25 ± 1.59 Length of follow up: NA Dep. Scale/Tool: SCID, CES-D, VAS-D | Inclusion criteria:; - 16 years or older; - Residence within Harris County (the catchment area for the trauma center); Exclusion criteria:; - Penetrating missile injury of the brain; - History of diagnosed schizophrenia; - Mental deficiency; - Hospitalization for previous TBI; - History of treatment for recent substance abuse; - Blood alcohol level exceeding 200 mg/dL when examined in the EC; TBI Def: Mild TBI: A closed head injury producing a period of unconsciousness no longer than 20 min in duration, lowest postresuscitation GCS score of 13 to 15, no extracranial injury that necessitated surgical repair under general anesthesia, and CT findings within 24 hr after injury indicating normal intracranial findings or a brain lesion that did not require surgical evacuation | Group(s): G1: Patients with mild/moderate TBI G1a: Patients with mild TBI G1b: Patients with moderate TBI G2: Patients with general trauma N screened: NR N eligible: NR N included: G1: 69 G2: 52 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: G1: 35.1 ± 14.7 G2: 36.3 ± 13.4 Age ≥16, n (%): 121 (100) Global injury severity (ISS), mean (range): G1: 5.9 (0–26) G2: 4.2 (0–17) Severity of TBI, n: Mild: G1a: 60 Moderate: G1b: 9 | Depression: SCID: DSM-IV criteria CES-D: NR VAS-D: NR Other co- morbidities: PTSD: PTSD Checklist Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Outcomes not reported separately for TBI (only for both groups combined) based on depression status | Depression, SCID, n : G1a: 11 G1b: 1 MDD, n (%): G1: 12 (17) G2: 3 (6) G1/G2: P = 0.09 CES-D score, mean ± SD: G1: 22.1 ± 15.2 G2: 17.2 ± 14.6 VAS-D score, mean ± SD: G1: 40.8 ± 36.7 G2: 23.8 ± 32.8 Taking depression medications: NR Other co- morbidities: PTSD, n (%): G1a: 8 (13) G1b: 0 PTSD checklist, mean ± SD: G1: 25.5 ± 17.3 G2: 17.2 ± 15.5 PTSD and MDD: G1: 4 Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR
Author: Lima et al., 2008 Country, Setting: Brazil, tertiary care center Enrollment Period: September 2004 to October 2004 Design: Cross-sectional Time from injury: At least 18 months Length of follow up: NA Dep. Scale/Tool: HADS | Inclusion criteria:; - GCS score between 13 and 15 with at least one of the following symptoms on hospital admission: headache, vertigo, amnesia, nausea, vomiting or LOC for less than 15 minutes; Exclusion criteria:; - Any history of head trauma (G2); TBI Def: Mild head trauma (MHT): A transient neurological deficit after a trauma resulting from acceleration and deceleration forces that cause impairment or LOC lasting less than 15 min, short retrograde amnesia, change in the level of consciousness without focal neurological deficits and GCS score between 13 and 15 at hospital admission | Group(s): G1: Patients with MHT G2: Participants living in the same household as G1 patients N screened: NR N eligible: G1: 41 N included: G1: 39 G2: 39 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI, %: G1: NR G2: 0 (see exclusion criteria) Age, yrs ± SD: G1: 39 ± 2.87 G2: 40 ± 2.14 Age ≥16: NR Global injury severity: NR Severity of TBI, GCS score: G1: 13 to 15 Injury on CT, n: G1: 6 No injury on CT, n: G1: 35 | Depression: HADS: 15–21: Abnormal 8–14: Borderline 0–7: Normal Other co-morbidities: PTSD: NR Other anxiety disorder: HADS, see depression cutoffs Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: SF-36 | Depression, n (%): Abnormal: G1: 9 (25.0) G2: 4 (11.1) Borderline: G1: 7 (19.4) G2: 6 (16.7) Taking depression medications: NR Other co-morbidities, n (%): PTSD: NR Other anxiety disorder: Abnormal: G1: 17 (47.2) G2: 8 (22.2) Borderline: G1: 9 (25.0) G2: 10 (27.8) Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status, SF36 domain scores, mean ± SD: Functional capacity: G1: 77.4 ± 3.6 G2: 93.0 ± 2.2 Physical aspects: G1: 57.7 ± 6.9 G2: 71.6 ± 6.1 Pain: G1: 59.2 ± 4.9 G2: 73.9 ± 4.1 Overall health condition: G1: 58.1 ± 5.1 G2: 76.1 ± 4.1
Author: Linn et al., 1994 Country, Setting: US, other Enrollment Period: NR Design: Cross-sectional Time from injury, mos ± SD: 70.3 ± 65.2 Length of follow up: NA Dep. Scale/Tool: SCL-90-R | Inclusion criteria:; - At least 1 year postinjury; Exclusion criteria: See inclusion criteria TBI Def: NR | Group(s): G1: TBI patients G2: Spouses N screened: NR N eligible: NR N included: G1: 60 G2: 60 N at conclusion: G1: 60 G2: 60 Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: G1: 40.8 ± 10.4 G2: 40.8 ± 9.9 Age ≥ 16, n (%): 120 (100) Global injury severity: NR Severity of TBI, PTA, n (%): ≤1 week: 9 (15.0) 1–2 weeks: 7 (11.6) > 2 weeks: 41 (68.3) LOC, days ± SD: 22.0 ± 41.2 | Depression: SCL-90 R depression subscale, T-scores: < 60: no elevation 60–69: mild elevation 70–79: moderate elevation > 79: severe elevation Other co-morbidities: PTSD: NR Other anxiety disorder: SCL-90 R anxiety sub-scale, T-scores: see depression cutoffs Irritability: NR Aggression: Social aggression scale Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Health and Activity Limitations Survey (HALS), including motor disability and sensory disability subscores | Depression, %: Severe: G1: 15.3 G2: 1.7 Moderate: G1: 13.6 G2: 26.7 Mild: G1: 40.7 G2: 45 SCL-90 R depression subscale, T-score, mean ± SD: G1: 63.9 ± 13.3 Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder: Anxiety, %: Severe: G1: 8.9 G2: 1.7 Moderate: G1: 8.9 G2: 20 Mild: G1: 32.1 G2: 33.3 SCL-90 R anxiety subscale, T-score, mean ± SD: G1: 62.1 ± 16.9 Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR
Author: MacNiven and Finlayson, 1993 Country, Setting: Canada, NR Enrollment Period: NR Design: Prospective cohort Time from injury: NR Length of follow up: 1–2 years Dep. Scale/Tool: MMPI | Inclusion criteria:; - Diagnosis of CHI; - Neurocognitive test results indicating competence to complete the MMPI; Exclusion criteria: See inclusion criteria TBI Def: NR | Group(s): Patients with CHI N screened: NR N eligible: NR N included: 59 N at conclusion: 14 Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, mean yrs: Men: 27 (n=42) Women: 22 (n=17) Age ≥16: NR Global injury severity: NR Severity of TBI: NR Mechanism/type of injury: NR Area of brain injured: NR Concomitant injuries: NR | Depression: MMPI: elevated score in scale 2 Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: Hypochondriasis: MMPI scale 1 Hysteria: MMPI scale 3 Psychopathic deviate: MMPI scale 4 Paranoia: MMPI scale 6 Psychasthenia: MMPI scale 7 Schizophrenia: MMPI scale 8 Hypomania: MMPI scale 9 Social introversion: MMPI scale 0 T-score ≥ 70: elevated MMPI scale Health related QoL or functional status: NR | Depression, elevated scale 2, (%): Initial assessment: 40.68 1 year: 40.7 2 years: 42.9 MMPI scale 2, T- score, mean ± SD: Initial assessment: 66.2 ± 14.3 1 year: 65.7 ± 15.4 Taking depression medications: NR Other co-morbidities, T-score, mean ± SD: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: Hypochondriasis: Initial assessment: 60.3 ± 19.8 1 year: 60.4 ± 10.2 Hysteria: Initial assessment: 61.8 ± 9.5 1 year: 61.4 ± 12.3 Psychopathic deviate: Initial assessment: 63.2 ± 10.4 1 year: 67.5 ± 12.8
Author: Marsh and Kersel, 2006 See Kersel et al., 2001 Country, Setting: New Zealand, tertiary care center Enrollment Period: April 1993 to August 1996 Design: Cross-sectional Time from injury, days ± SD: 386 ± 31 Length of follow up: NA Dep. Scale/Tool: HIBS | Inclusion criteria:; - Ventilation on clinical grounds was required for > 24 hours, at least in part, for treatment of TBI; - Between 16 and 70 years of age; Exclusion criteria:; - Non-English speaking; - Previous hospital admission for TBI or psychiatric illness; TBI Def: NR^*^ | Group(s): Patients with TBI and caregivers nominated by family members N screened: NR N eligible: 123 N included: 62 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: 28 ± 11 Age ≥16, n (%): 62 (100) Global injury severity: NR Severity of TBI, n (%): Severe: 50 (81) Moderate: 9 (15) Mild: 3 (5) Mechanism/type of injury, n (%): Road traffic crash: 47 (76) Fall: 6 (10) Assault: 5 (8) Other: 4 (7) | Depression: HIBS, self-report and caregiver versions: NR Other co-morbidities: PTSD: NR Other anxiety disorder: HIBS Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: GOS: Severe disability, Moderate disability, Good recovery | Depression, n (%): Self-report: 32 (52) Caregivers: 32 (52) Taking depression medications: NR Other co-morbidities, n (%): PTSD: NR Other anxiety disorder: Self-report: 28 (45) Caregivers: 32 (52) Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: GOSE, n (%): Severe disability: 15 (24) Moderate disability: 13 (21) Good recovery: 34 (55)
Author: McCauley et al., 2005 See Levin et al., 2005 Country, Setting: US, trauma center Enrollment Period: January 1999 to April 2003 Design: Cross-sectional Time from injury, days ± SD: 86.4 ± 17.4 Length of follow up: NA Dep. Scale/Tool: SCID, CES-D, VAS-D | Inclusion criteria:; - Arrival to hospital within 24 hours of injury; - Blood alcohol level < 200 mg/dL; - Age 16 years or older; - Fluent in English or Spanish; - Residing in the hospital catchment area (Harris County, TX); - Diagnosis of non-penetrating TBI; - Lowest post-resuscitation GCS > 8; - CT scan of the brain performed within 24 hours of arrival; Exclusion criteria:; - Undocumented alien, incarcerated, homeless, or on active military service; - Spinal cord injury; - Previous TBI requiring hospitalization; - History of substance dependence, mental retardation, major psychiatric disorders, or other central nervous system disturbance | Group(s): G1: Postconcussional disorder, DSM-IV criteria G2: No PCD G3: Postconcussional syndrome, ICD-10 criteria G4: No PCS N screened: NR N eligible: 854 N included: Total: 340 G1: 59 G2: 281 G3: 183 G4: 157 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: 32.3 ± 13.5^*^ Age ≥16, n (%): 340 (100) Global injury severity, ISS not including head region, mean ± SD: G1: 3.0 ± 4.6 G2: 4.6 ± 5.6 G3: 4.0 ± 5.3 G4: 4.6 ± 5.6 | Depression: SCID: DSM-IV criteria CES-D: NR VAS-D: NR Other co-morbidities: PTSD (PTSD Checklist-Civilian Form; SCID PTSD) and anxiety grouped together Other anxiety disorder: see PTSD Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: GOS-E | Depression, SCID, current MDE, n (%): G1: 28 (47.5) G2: 23 (8.2) G3: 48 (26.2) G4: 3 (1.9) CES-D score, mean ± SD: G1: 33.9 ± 1.7 G2: 17.5 ± 0.9 G3: 26.1 ± 1.0 G4: 11.2 ± 1.1 VAS-D score, mean ± SD: G1: 57.5 ± 4.2 G2: 29.1 ± 2.4 G3: 45.8 ± 2.5 G4: 15.9 ± 2.8 Taking depression medications: NR Other co-morbidities: PTSD/Anxiety: SCID-PTSD, n (%): G1: 21 (35.6) G2: 18 (6.4) G3: 33 (18.0) G4: 6 (3.8) PCL-C score, mean ± SD: G1: 38.2 ± 1.9 G2: 17.1 ± 1.1 G3: 29.1 ± 1.1 G4: 9.5 ± 1.2 Other anxiety disorder: see PTSD Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR
Author: McCauley and Boake et al., 2001 See Levin et al., 2001 Country, Setting: US, tertiary care center Enrollment Period: NR Design: Prospective cohort Time from injury, days ± SD : 31.4 ± 8.1; 87.7 ± 21.8 Length of follow up: 3 months Dep. Scale/Tool: SCID, CES-D, VAS-D | Inclusion criteria:; - At least 16 years of age; - Non-penetrating head injury (G1); - CT scan performed within 24 hrs of injury (G1); - Fluency in English or Spanish; Exclusion criteria:; - Previous hospitalization for head trauma; - Preinjury major neuropsychiatric disorder; - Preinjury substance dependence (including alcohol); - Pre-existing CNS disturbance (e.g., HIV/AIDS, seizure disorder, strokes, Parkinsonism, etc.); - Associated spinal cord injury; - Undocumented resident status; - Blood alcohol level (BAL) ≥ 200 mg/dL when the GCS score was obtained without external signs of head trauma and in conjunction with a normal CT scan (G1); - Surgery with general anesthesia for extracranial injuries | Group(s): G1: Patients with TBI G1a: Patients with mild TBI G1b: Patients with moderate TBI G2: Patients with general trauma N screened: NR N eligible: NR N included: G1: 115 G2: 85 N at conclusion: G1: 115 G2: 85 Depression, n (%): Prior to injury: G1a: 7 (7.9) G1b: 3 (11.5) G2: 7 (8.2) At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI (%): NR Age, time of injury, yrs ± SD: G1: 33.4 ± 13.7 G2: 34.5 ± 12.5 Age ≥16, n (%): 200 (100) Global injury severity (ISS), mean ± SD: G1: 4.9 ± 6.1 G2: 3.7 ± 4.4 | Depression: SCID: DSM-IV criteria CES-D: NR VAS-D: NR Other co-morbidities: PTSD: SCID PCL-C Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Outcomes not reported by depression status | Depression, SCID, n (%): Current MDD, n (%): G1a: 19 (21.4) G1b: 6 (23.1) G2: 14 (16.5) CES-D score, mean ± SD: G1: 22.5 ±14.7 G2: 19.1 ± 14.1 VAS-D score, mean ± SD: G1: 40.1 ± 34.8 G2: 28.8 ± 32.1 Dysthymia, n: Total: 2 Taking depression medications: NR Other co-morbidities: PTSD, SCID, n (%): G1a: 11 (12.4) G1b: 4 (15.4) G2: 12 (14.1) PCL-C score, mean ± SD: G1: 24.3±16.7 G2: 20.9 ± 17.2 Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: PCD, n (%): G1a: 27 (33.0) G1b: 8 (30.8) G2: 13 (15.3) MDD among PCD patients, %: 47.9
Author: McCauley and Levin et al., 2001 Country, Setting: US, trauma centers Enrollment Period: October 1994 to November 1998 Design: Prospective cohort Time from injury, days ± SD: 94.1 ± 10.2 Length of follow up: 6 months Dep. Scale/Tool: NRS-R | Inclusion criteria:; - 15 to 65 yrs old; - Abnormal CT within 24 hrs of injury; - Postresuscitation GCS motor score of 1 to 5 (total GCS ≤ 8); Exclusion criteria:; - Evidence of hypotension (systolic BP < 90 mm Hg for ≥ 30 mins after resuscitation); - Hypoxia (saturation < 94%) for 30 minutes after resuscitation; - Estimated AIS score of ≥ 4 for any organ system; - GCS of 3 with uncreative pupils; - Inability to randomize within 6 hours of injury; TBI Def: NR^*^ | Group(s): G1: Patients with severe closed HI meeting inclusion criteria G2: Patients with severe closed HI not meeting inclusion criteria N screened: 392 N eligible: 392 N included: G1: 315 G2: 77 N at conclusion: G1: 210 G2: 77 Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: G1: 29.5 ± 11.0 G2: 35.4 ± 13.4 Age ≥16: NR Global injury severity: NR Severity of TBI, GCS score, mean ± SD: G1: 6.0 ± 1.2 G2: 5.4 ± 1.3 | Depression: NRS-R: NR Other co-morbidities: PTSD: NR Other anxiety disorder: NRS-R Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NRS-R Health related QoL or functional status: Cognitive battery: (Buschke verbal selective reminding test, immediate and delayed recall trials of the Rey-Osterrieth complex figure, trial making test B, symbol digit modalities, grooved peg board, controlled oral word association test) | Depression, 6 months, %: Severe: 0.5 Moderate: 15.7 Mild: 34.8 Taking depression medications (%): NR Other co-morbidities, %: PTSD: NR Other anxiety disorder: Severe: 0 Moderate: 10.0 Mild: 36.7 Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: Liability of mood: Severe: 0.5 Moderate: 3.3 Mild: 21.9 Unusual thought content: Severe: 0.5 Moderate: 1.0 Mild: 12.4 Disinhibition: Severe: 1.0 Moderate: 4.3 Mild: 12.9 Hyperactivity/agitation: Severe: 0.5 Moderate: 1.0 Mild: 11.4
Author: McCleary et al., 1998 See Satz et al., 1998 & Satz et al., 1998 Country, Setting: US, tertiary care centers Enrollment Period: 1991 to 1995 Design: Prospective cohort Time from injury: 12 months Length of follow up: 12 months Dep. Scale/Tool: SCL-90-R, NRS | Inclusion criteria:; - At least 16 yrs old; - Moderate to severe TBI (G1); - GCS score of 12 or less, or GCS score of 13 or higher if abnormalities noted on the admission CT scan, or if the condition deteriorated to below 13 on the GCS prior to discharge (G1); - Bodily injuries other than to the head (G2); Exclusion criteria: See inclusion criteria TBI Def: NR^*^ | Group(s): G1: Patients with TBI G2: Other injury patients matched by age, gender, and AIS score N screened: NR N eligible: NR N included: G1: 105 G2: 40 N at conclusion: G1: 66 G2: 25 Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: G1: 31.1 ± 13.1^ G2: 34.1 ± 11.7 Age ≥16, n (%): 145 (100) Global injury severity: NR Severity of TBI (GCS): All patients had moderate to severe injury Mechanism/type of injury: NR | Depression: SCL-90-R: > 2 SD above the mean NRS: scores of 4–7 on item 13 Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Based on GOS: ≥ 3 Severe disability Moderate disability Good recovery | Depression, n (%): SCL-90-R and NRS, 6 mos: G1: 44/105 (41.9) G2: 8/40 (20) SCL-90-R and NRS, 12 mos: G1: 24/66 (36.3) G2: 8/26 (30.8) SCL-90-R, 6 mos: G1: 23/94 (24.4) G2: 5/33 (15.2) SCL-90-R, 12 mos: G1: 11/55 (20) G2: 3/21 (14.3) NRS, 6 mos: G1: 34/103 (33) G2: 4/40 (10) NRS, 12 mos: G1: 22/66 (33.3) G2: 7/26 (26.9) Depressed at both 6 and 12 months, n (%): G1: 17/24 (70.8)^*^ G2: 3/6 (50) Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR
Author: Mobayed and Dinan, 1990 Country, Setting: Ireland, tertiary care center Enrollment Period: NR Design: Cross-sectional Time from injury: 11 to 13 months Length of follow up: NA Dep. Scale/Tool: DSM-III, Leeds Scales for Anxiety and Depression | Inclusion criteria:; - 18 to 65 yrs old; - Negative neurological exam on admission and discharge; - No medical complications; - Closed mild head injury (MHI); Exclusion criteria: See inclusion criteria TBI Def: MHI: LOC for < 20 mins, and hospitalization for < 3 days | Group(s): Patients with MHI N screened: 70 N eligible: 55 N included: 55 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: History of affective disorder: 0 Family history of affective disorder, epilepsy, cognitive impairment, alcohol abuse or significant social stresses: 0 N with prior TBI: NR Age, yrs ± SD: Patients with depression: 30.63 ± 2.39 (n=11) Patients without depression: 32.75 ± 2.27 (n=8) Age ≥16, n (%): 55 (100) Global injury severity: NR Severity of TBI, n (%): MHI: 55 (100) | Depression: DSM-III criteria Leeds self-rating questionnaire : Cutoff score of 6–7 for anxiety and depression Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, DSM-III, n (%): MDD: 11/32 (34.4) Affective disorder, Leeds, n (%): 16/55 (29.1) Taking depression medications, n (%): 1 (1.8)(diazepam, anti-anxiety) Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR
Author: Mollica et al., 2009 Country, Setting: US, other Enrollment Period: May 2002 to June 2004 Design: Cross-sectional Time from injury, years : NR Length of follow up: NA Dep. Scale/Tool: HSCL | Inclusion criteria:; - South Vietnamese ex-political detainee who had been tortured in Vietnamese reeducation camps and resettled in the US; Exclusion criteria: See inclusion criteria TBI Def: Concussion associated traumatic head injury (THI): 1 or more occasions during which all 3 postconcussive symptoms (LOC, PTA, and any neurologic deficits) occurred | Group(s): G1: Ex-political detained G1a: With THI G1b: Without THI G2: Non-reeducation camp, non-THI Vietnamese comparison group N screened: G1: 337 G2: 82 N eligible: G1: 337 G2: 82 N included: G1: 42 G1a: 16 G1b: 26 G2: 16 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI (%): NR Range of “trauma/torture” exposures: 5–40 Age, yrs ± SD: G1: 62.9 ± 8.0 G2: 62.6 ± 9.6 Age ≥16, N (%): 58 (100) Global injury severity: NR | Depression: Hopkins Symptom Checklist-25: 15 item scale for depression; cutoff of 1.75 for depression Other co-morbidities: PTSD: Harvard Trauma Questionnaire Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, HSCL n (%): G1a: 10/16 (62.5) G1b: 3/26 (11.5) G2: 6/16 (37.5) Taking depression medications (%): NR Other co-morbidities: PTSD: HTQ, n (%): G1a: 8/16 (50.0) G1b: 4/26 (15.4) G2: 0/16 Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR Multivariate model predictors: Right overall cerebral cortical thickness was negatively correlated with HSCL scores (r = −0.6, P = 0.02) Left overall cerebral cortical thickness was not correlated with HSCL scores (r = −0.6, P = 0.05)
Author: Mooney et al., 2005 See Mooney and Speed, 2001 Country, Setting: US, tertiary care center Enrollment Period: NR Design: Cross-sectional Time from injury, median: 15 months Length of follow up: NA Dep. Scale/Tool: DSM-IV, BDI-II | Inclusion criteria:; - Outpatient of mild TBI clinic of the tertiary care center; Exclusion criteria: See inclusion criteria TBI Def: According to ACRM criteria | Group(s): Patients with TBI N screened: NR N eligible: NR N included: 67 N at conclusion: NA Depression, n (%): Prior to injury: 21 (34) At time of injury: NR Other preexisting psychiatric conditions, n (%): Lifetime history of prior mental health problems: 36 (54) Anxiety disorder: 6 (9) N with prior TBI (%): 17 (25) Age, yrs ± SD: 41.4 ± 13.3 Age ≥16, n (%): 67 (100) Global injury severity: NR Severity of TBI, n (%): LOC: 4 (6) Amnesia: 47 (70) Dazed/confused at time of injury: 16 (24) | Depression: DSM-IV criteria BDI-II; participant and/or family member interview used to determine depression status pre-TBI Other co-morbidities: PTSD: NR Other anxiety disorder: participant and/or family member interview used to determine anxiety status pre-TBI Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: participant and/or family member interview used to determine mental health history pre-TBI Health related QoL or functional status: NR | Depression, MDD, %: 61 BDI-II score, mean ± SD: Total: 22.0 ± 12.4 Disabled: 22.2 ± NR (n=47) Non-disabled: 16.6 (n=19) P = 0.03 Correlation with BDI-II scores: Headache: 0.2 (P = 0.07) Non-cephalic pain: 0.3 (P = 0.05) PCS checklist scores: 0.6 (P < 0.001) Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety Disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses, moderate-severe, %: Headache: 72 Non-cephalic pain: 64 Dizziness: 32 Vertigo: 15 Health related QoL or functional status: NR
Author: Mooney and Speed, 2001 See Mooney et al., 2005 Country, Setting: US, TBI rehabilitation center Enrollment Period: NR Design: Cross-sectional Time from injury, weeks (median): 24.50 Length of follow up: NA Dep. Scale/Tool: DSM-IV | Inclusion criteria:; - Mild TBI; Exclusion criteria: See inclusion criteria TBI Def: According to ACRM criteria | Group(s): Patients with actual or suspected mild TBI N screened: NR N eligible: NR N included: 80 N at conclusion: NA Depression, n (%): Prior to injury: 12 (15) At time of injury: NR Other preexisting psychiatric conditions, n (%): Anxiety: 2 (3) Other psychiatric condition: 9 (11) Alcohol an injury related factor: (NR) 11 N with prior TBI: NR Age, yrs ± SD: 31.1 ± 13.4 Age ≥16: NR Global injury severity: NR | Depression: DSM-IV criteria Other co-morbidities: PTSD: Impact of event scale Other anxiety disorder: BSQ Fear survey Irritability: NR Aggression: NR Suicidality: NR Substance use: Self-report/presence of positive blood alcohol levels noted in the clinical record Other psychiatric diagnoses: MMPI DES Health related QoL or functional status: POMS Post-concussion symptom check-list Complex partial seizure check list Cognitive function (WAIS-R, WMS-R, Auditory verbal learning test, Trail making test) | Depression, n (%): 35 (44) Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety Disorder, n (%): 19 (24) Irritability: NR Aggression: NR Suicidality: NR Substance use: Diagnosis, n (%): TBI only: 17 (21) Psychiatric condition only: 13 (16) TBI and psychiatric condition: 48 (60) No diagnosis: 2 (3) Other psychiatric diagnoses, n (%): MMPI: 6 (8) DES score, mean ± SD: 13.8 ± 12.6 DES score, poor recovery group, mean: 20.14 Health related QoL or functional status: NR
Author: Parcell et al., 2006 See Curran et al., 2000 Country, Setting: Australia, tertiary care center Enrollment Period: NR Design: Cross-sectional Time from injury, mean: G1: 230 days G2: NA Length of follow up: NA Dep. Scale/Tool: HADS | Inclusion criteria:; - 16 to 65 yrs old; - Sufficient English language ability to complete the questionnaires; Exclusion criteria:; - Transmeridian travel across more than 1 time zone in the preceding 3 months and no shift work in the previous 12 months; - Preinjury sleep disorder, as indicated by significant other‘s responses on a screening checklist for classic symptoms of periodic limb movement disorder, sleep apnea, or insomnia; - Taking benzodiazepines or other sleeping medications; - Previous head injury, neurologic disorder, or major psychiatric disorder; TBI Def: NR^*^ | Group(s): G1: Participants with TBI G2: Age and sex matched uninjured participants N screened: NR N eligible: NR N included: G1: 63 G2: 63 N at conclusion: G1: 63 G2: 63 Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: None (see exclusion criteria) Age, yrs ± SD: G1: 32.5 ± 1.7 G2: 30.5 ± 1.2 Age ≥16, n (%): 126 (100) Global injury severity: NR | Depression: HADS: 15–21: Severe 11–14: Moderate 8–10: Mild Other co-morbidities: PTSD: NR Other anxiety disorder: HADS, see depression scale for cutoffs Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, %: Severe: G1: 5 G2: 0 Moderate: G1: 6 G2: 0 Mild: G1: 27 G2: 2 HADS score, mean ± SD: G1: 5.8 ± 0.5 G2: 2.1 ± 0.3 G1/G2: P < 0.01 Depression and GCS, correlation: 0.19 P = 0.15 Taking depression medications (%): NR Other co-morbidities, %: PTSD: NR Other anxiety disorder: Anxiety: Severe anxiety: G1: 3 G2: 3 Moderate anxiety: G1: 19 G2: 5 Mild anxiety: G1: 18 G2: 18 HADS, anxiety score, mean ± SD: G1: 6.7 ± 0.6 G2: 5.7 ± 0.5 G1/G2: P = 0.17 Irritability: NR Aggression: NR Suicidality: NR
Author: Peleg et al., 2009 Country, Setting: Israel, rehabilitation centers Enrollment Period: NR Design: Cross-sectional Time from injury, yrs ± SD: 2.9 ± 2.3 Length of follow up: NA Dep. Scale/Tool: BDI | Inclusion criteria:; - 18 to 60 yrs old; - Medically documented TBI occurring at least 6 mos prior to the study; - Able to give consent; - Cognitively apt to answer different questionnaires; - Non-psychotic; - No report of depression prior to TBI onset; Exclusion criteria: See inclusion criteria TBI Def: NR^*^ | Group(s): Participants with TBI N screened: NR N eligible: 82 N included: 65 N at conclusion: NA Depression: Prior to injury: None, see inclusion criteria At time of injury: None, see inclusion criteria Other preexisting psychiatric conditions: NR N with prior TBI (%): NR Age, yrs ± SD: 28.8 ± 9.0 Age ≥16, N (%): 65 (100) Global injury severity: NR Severity of TBI^†^, %: Mild: 31 Moderate: 8 Severe: 61 GCS, mean ± SD (range): 8.7 ± 4.2 (3–15) Mechanism/type of injury, %: Road accidents: 75.4 War accidents: 12.3 Falls: 12.3 | Depression: BDI: cutoffs NR Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, BDI, n (%): Mild: 19 (29.2) Moderate: 15 (23.1) Severe: 14 (21.5) BDI score, mean ± SD: 19.3 ± 11.7 Taking depression medications (%): NR Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR Multivariate model predictors: Adult Hope Scale score: P < 0.005 Life Orientation Test Revised score: P < 0.05
Author: Perlesz et al., 2000 See Curran et al., 2000 Country, Setting: Australia, multicenter Enrollment Period: NR Design: Cross-sectional Time from injury: 1 to 5 years Length of follow up: NA Dep. Scale/Tool: BDI | Inclusion criteria:; - At least 16 yrs old; - 1 to 5 years postinjury; - Discharged to home care following acute rehabilitation; Exclusion criteria:; - No interest in participating (36, 22.4%); - Minor head injury and discussion with researcher leading to decision that participation was not relevant (17, 10.6%); - Anger with rehabilitation system and refusal to participate (5, 3.1%); - Failure to return questionnaires (24, 14.9%); TBI Def: Mild: PTA 5–59 minutes Moderate: PTA 1–23 hours Severe: PTA 1–6 days Very Severe: PTA 1–4 weeks Extremely severe: PTA 1–3 months Profoundly severe: PTA > 3 months | Group(s): G1: Patients with TBI G2: Relatives N screened: 223 families of TBI patients N eligible: 161 families N included: G1: 65 G2: 147 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI (%): G1: 7 (11) G2: NR Age, yrs ± SD: G1: 33.8 ± 15.0 G2: NR Age ≥16, n (%): 212 (100) Global injury severity: NR | Depression: BDI: score > 10 indicates borderline or clinical depression Other co-morbidities: PTSD: NR Other anxiety disorder: STAI > 80^th^ percentile Irritability: NR Aggression: NR Suicidality: NR Substance use: data gathered on Head Injury Family Interview (HI-FI) demo-graphic and pre-injury form Other psychiatric diagnoses: POMS: score ≥ 73 indicates a clinical level of mood disturbance Health related QoL or functional status: Family Satisfaction Scale (FSS): midpoint of 32.5 indicates dissatisfaction with the family | Depression, n (%): 37/62 (59.7) Taking depression medications: NR^*^ Other co-morbidities, n (%): PTSD: NR Other anxiety disorder: 31/62 (50) Irritability: NR Aggression: NR Suicidality: NR Substance use: Alcohol: Severe: 0 (0) Moderate: 5 (7.7) Drugs : Severe: 0 (0) Moderate: 6 (9.2) Other psychiatric diagnoses: POMS: Anger: 35/61 (57.4) Fatigue: 35/61 (57.4) Health related QoL or functional status: Family dissatisfaction, n (%): 10/41 (24.4)
Author: Ponsford and Schönberger 2010 Country, Setting: Australia, tertiary care center Enrollment Period: NR Design: Cross-sectional Time from injury, years : 2, 5 Length of follow up: NA Dep. Scale/Tool: HADS | Inclusion criteria:; - Participants with TBI who had received rehabilitation in the context of a no-fault accident compensation system; Exclusion criteria: See inclusion criteria TBI Def: NR^*^ | Group(s): Participants with TBI N screened: NR N eligible: NR N included^†^: 2 yrs: 301 5 yrs: 266 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI (%): NR Age at injury, yrs ± SD (range): 2 yrs: 34.5 ± 15.9 (15–82) 5 yrs: 34.6 ± 16.7 (14–87) Age ≥16, N (%): NR Global injury severity: NR Severity of TBI: GCS, mean ± SD: 2 yrs: 7.9 ± 4.4 5 yrs: 7.4 ± 4.2 Range 3–15 at both time points | Depression: HADS: clinically significant depression if score >7 Other co-morbidities: PTSD: NR Other anxiety disorder: HADS: clinically significant anxiety if score >7 Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, %: 2 yrs: 45 5 yrs: 44 p=NS Taking depression medications (%): NR Other co-morbidities, %: PTSD: NR Other anxiety disorder: 2 yrs: 53 5 yrs: 49 p=NS Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR
Author: Popovic et al., 2004 Country, Setting: Serbia, tertiary care center Enrollment Period: NR Design: Cross-sectional Time from injury, yrs ± SD: 3.8 ± 0.7 Length of follow up: NA Dep. Scale/Tool: ZDS, SCL-90-R | Inclusion criteria:; - Moderate-to-severe TBI; - At least 1 year after hospitalization; - Not treated with glucocorticoids while in the ICU; Exclusion criteria: See inclusion criteria TBI Def: Moderate TBI: GCS of 9 to 13 Severe TBI: GCS of < 8 | Group(s): G1: Patients with moderate-to-severe TBI G2: Healthy participants N screened: NR N eligible: NR N included: G1: 67 G2: 78 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: G1: 37.5 ± 1.8 G2: 37.2 ± 1.4 Age ≥16: NR Global injury severity: NR Severity of TBI, n (%): Moderate to severe: G1: 67 (100) Mechanism/type of injury: NR | Depression: ZDS > 39 SCL-90-R: NR Other co-morbidities: PTSD: NR Other anxiety disorder: SCL-90-R Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, ZDS, n (%): Total: 19/41 (46.3) Strong intensity of depression: 8/41 (19.5) Mild to moderate depression: 11/41 (26.8) ZDS score, mean: 41.2 SCL-90-R, depression dimension, T-score: 0.51 Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder: SCL-90-R, phobic anxiety dimension, T-score: 0.57 SCL-90-R, psychoticism dimension, T-score: 0.53 Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR
Author: Powell et al., 2002 Country, Setting: UK, tertiary care center Enrollment Period: NR Design: Prospective cohort Time from injury, yrs ± SD: G1: 4.0 ± 4.9 G2: 2.7 ± 3.6 Length of follow up: 18 to 40 months Dep. Scale/Tool: HADS | Inclusion criteria:; - 16 to 65 yrs old; - TBI as verified by hospital or general practitioner records; - No concurrent neurological diagnoses; - Living within 1 hour travel time of the hospital; - Long term treatment goals agreed within the team as being amenable in principle to intervention; Exclusion criteria: See inclusion criteria TBI Def: NR | Group(s): G1: Outreach group G2: Information group N screened: 166 N eligible: 110 N included: G1: 54 G2: 56 N at conclusion: G1: 48 G2: 46 Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: G1: 34 ± 11 (n=48) G2: 35 ± 10 (n=46) Age ≥16, n (%): 110 (100) Global injury severity: NR | Depression: HADS > 10 Other co-morbidities: PTSD: NR Other anxiety disorder: HADS > 10 Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: FIM+FAM Unmodified Barthel Index 20: Physical independence Brain Injury Community Rehabilitation Outcome-39 scales (BICRO-39) | Depression, %: Total: 35 HADS > 13: 15 HADS score, intake, mean ± SD: G1: 7.7 ± 4.2 G2: 8.5 ± 5.0 HADS, follow-up, mean change ± SD: G1: 0 ± 4.2 G2: 0.4 ± 4.0 HADS, improved at follow-up, n (%): G1: 10/20 (50) G2: 14/26 (53.8) Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder, %: Total: 29 HADS > 13: 15 HADS score, intake, mean ± SD: G1: 8.7 ± 4.1 G2: 8.3 ± 4.8 HADS, follow-up, mean change ± SD: G1: 0.5 ± 4.1 G2: −0.6 ± 3.8 HADS, improved at follow-up, n (%): G1: 10/20 (50) G2: 9/26 (34.6) Irritability: NR Aggression: NR Suicidality: NR
Author: Rao et al., 2009 See Rao et al., 2008 Country, Setting: US, tertiary care centers Enrollment Period: NR Design: Cross-sectional Time from injury, mos: <3 Length of follow up: NA Dep. Scale/Tool: SCID | Inclusion criteria:; - At least 18 yrs old Ability to provide consent; - Admission to hospital for evaluation of head trauma; Exclusion criteria:; - Prior TBI; - Open-head injury; - History of any other type of brain illness; TBI Def: At least one of the following: clear history of LOC; GCS score less than 15; evidence of trauma on CT scan done as part of clinical workup Mild: GCS score of 13 to 15 Moderate: GCS score of 9 to 12 Severe: GSC score of 3 to 8 Participants with mild TBI also met ACRM criteria | Group(s): Patients with TBI N screened: NR N eligible: 107 N included: 67 N at conclusion: NA Depression: Prior to injury, n (%): 6 (9.0) At time of injury: NR Other preexisting psychiatric conditions, n (%): Any axis 1 diagnosis: 51 (76.1) Alcohol abuse/dependence: 35 (52.2) Substance abuse/dependence: 33 (49.3) N with prior TBI (%): None, see exclusion criteria Age, yrs ± SD: 42.6 ± 17.7 Age ≥16, N (%): 67 (100) Global injury severity: General Medical Health Rating score, % Poor: 9 Fair: 21 Good: 40 Excellent: 30 | Depression: SCID: DSM-IV criteria Other co-morbidities: PTSD: NR Other anxiety disorder: SCID Irritability: NR Aggression: OAS Suicidality: NR Substance use: NR Other psychiatric diagnoses: SCID Health related QoL or functional status: NR | Depression, n (%): 8 (11.9)^*^ Taking depression medications (%): NR Other co-morbidities, n (%): PTSD: NR Other anxiety disorder: 12 (17.9) Irritability: NR Aggression: Total sample: 19 (28.4) 5/8 (62.5) participants with depression and aggression Suicidality: NR Substance use: NR Other psychiatric diagnoses: Postconcussion syndrome: 11 (16.4) Health related QoL or functional status: NR
Author: Rao et al., 2008 See Rao et al., 2009 Setting: US, tertiary care centers Enrollment Period: NR Design: Cross-sectional Time from injury, range: 0 to 3 months Length of follow up: 1 to 3 months Dep. Scale/Tool: SCID | Inclusion criteria:; - At least 18 years of age; - Ability to provide consent; Exclusion criteria:; - Prior TBI; - Open-head injury; - History of brain illness; - No admission to hospital; - Absence of clear history of LOC; TBI Def: At least one of following: admitted to the hospital with clear history of loss of consciousness; GCS score of 15 or less; and/or evidence of trauma on computerized tomography (CT) scans done as part of clinical workup Mild: GCS score of 13 to 15 Moderate: GCS score of 9 to 12 Severe: GSC score of ≤ 8 | Group(s): Patients with TBI N screened: ~1,000 N eligible: NR N included: 54 N at conclusion: 54 Depression, n (%): Prior to injury: 5 (9.3) At time of injury: NR Other preexisting psychiatric conditions, n (%): Anxiety disorder: 4 (7.4) N with prior TBI: None, see exclusion criteria Age, yrs ± SD: 43.2 ± 17.7 Age ≥16, n (%): 54 (100) Global injury severity: NR Severity of TBI, GCS, %: Mild: 65.0 Moderate: 11.0 Severe: 19.0 Unknown: 5.5 Mechanism/type of injury, %: MVA: 52.0 Assault: 24.0 Falls: 22.0 UNK: 2.0 | Depression: SCID: DSM-IV criteria Other co-morbidities: PTSD: NR Other anxiety disorder: SCID Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: MOS | Depression, n (%): Major depressive-like episode: 7 (13.0) Taking medications: NR Other co-morbidities, n (%): PTSD: NR Other anxiety disorder: General anxiety: 6 (11) Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status, MOS, mean ± SD: Sleep disturbance: Pre-TBI: 17.5 ± 15.9 Post-TBI: 27.7 ± 24.1 P = 0.018 Snoring: Pre-TBI: 18.4 ± 30.2 Post-TBI: 14.5 ± 26.9 P = 0.4 SOB/HA: Pre-TBI: 0.39 ± 2.8 Post-TBI: 14.1 ± 27.5 P = 0.001 Sleep adequacy: Pre-TBI: 26.7 ± 28.2 Post-TBI: 38.6 ± 31.1 P = 0.023
Author: Rapoport et al., 2008 Country, Setting: Canada, tertiary care center Enrollment Period: NR Design: Case series Time from injury: NR Length of follow up: 10 weeks Dep. Scale/Tool: SCID, HAM-D | Inclusion criteria: See exclusion criteria Exclusion criteria:; - Prior focal brain disease (e.g., stroke, tumor); - Significant acute medical illness; - Alcohol abuse; - CT abnormalities inconsistent with TBI; - Current antidepressant treatment; - Contraindications to citalopram; - Premorbid diagnosis of schizophrenia, bipolar disorder or dementia; TBI Def: Mild TBI: LOC at the time of the injury of 20 min or less, an initial GCS of 13 to 15, PTA < 24 hrs and a normal CT brain image. Moderate-to-severe TBI: GCS < 13, PTA > 24 hrs or an abnormal CT brain image | Group(s)^*^: G1: 6 week citalopram trial, various doses G2: 10 week citalopram trial, various doses N screened: NR N eligible: NR N included^*^: G1: 65 G2: 26 N at conclusion^*^: G1: 54 G2: 26 Depression, n (%): Prior to injury: 7/65 (10.8) At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: 39.7 ± 19.0 Age ≥16, n (%): 65 (100) Global injury severity: NR Severity of TBI, n (%): Mild: 33/65 (50.8) Mod-Severe: 32/65 (49.2) Mechanism/type of injury: NR | Depression: SCID: DSM-IV criteria; at least 5 out of 9 symptoms, one of which must be either depressed mood or anhedonia Response ≥ 50% in HAMD score Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression: MDD, n (%): 54 (83.1) HAMD score, base-line, mean ± SD: 23.7 ± 6.6 HAMD score, 6 weeks, mean ± SD: 16.3 ± 9.3 (n=59) p<.0001 Responded, 6 weeks, n (%): 15/54 (27.7) Remission, 6 weeks, n (%): 13/54 (24.1) HAMD score, 10 weeks, mean ± SD: 13.0 ± 7.9 (n=26) p<.0001 Responded, 10 weeks, n (%): 12/26 (46.2) Remission, 10 weeks, n (%): 7/26 (26.9) Taking depression medications, %: Completed trial: 83.1 Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR
Author: Rapoport, Herrmann et al., 2006 See Rapoport, Kiss et al., 2006 Country, Setting: Canada, rehabilitation center Enrollment Period: NR Design: Prospective cohort Time from injury: 1 year Length of follow up: 1 year Dep. Scale/Tool: SCID | Inclusion criteria:; - Age 50 and over and within 2 months of injury (G1); - Non-injured participants matched by age decade, education, and gender (G2); Exclusion criteria:; - A pre-injury history of neurologic disease, serious acute medical illness, schizophrenia, or bipolar disorder; - Preexisting cognitive decline based on history and a score of > 3.38 on the Informant Questionnaire for Cognitive Decline in the Elderly (IQCODE); - Lack of an informant to complete the IQCODE; TBI Def: Mild TBI: Loss or alteration of consciousness at the time of injury for ≤ 20 minutes, an initial GCS of 13 to 15, and PTA of < 24 hour | Group(s): G1: Participants with TBI G2: Participants without TBI N screened: G1: 712 G2: 79 N eligible: G1: 248 G2: 79 N included: G1: 69 G2: 69 N at conclusion: G1: 49 G2: 69 Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: None (see exclusion criteria) N with prior TBI (%): Mild TBI: G1: 8 (11.8) G2: 5 (6.3) Age, yrs ± SD: G1: 67.0 ± 7.9 G2: 68.0 ± 8.5 Age ≥16, n (%): 138 (100) Global injury severity: NR Severity of TBI, n (%): Moderate: 14 (20.1) Complicated Mild: 18 (26.1) Mild: 37 (53.6) | Depression: SCID: DSM-IV Subsyndromal depression: minimum of three DSM-IV symptoms of a major depressive episode, at least one of which is persistent depressed mood or anhedonia, lasting for two weeks Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: Dementia: Mattis Dementia Rating Scale (DRS) and MMSE Health related QoL or functional status: Psychologic distress: GHQ Informant ratings: FAQ | Depression, baseline, n (%): Major Depression: G1: 11/69 (15.9) G2: 0 Subsyndromal depression: G1: 15/69 (21.7) G2: 3/79 (3.8 ) Depression, 1 year, n (%): Major depression: G1: 6^*^/49 (12.2) G2: 1/68 (1.5) Subsyndromal depression: G1: 9 (18.8) G2: 2 (2.9) Taking depression medications, n (%): G1: 10 (14.5) G2: 3 (4) Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: Dementia: DRS score, mean: G1: 135.4 ± 8.5 G2: 139.0 ± 3.7 MMSE, mean: G1: 28.2 ± 1.9 G2: 29.1 ± 1.2
Author: Rapoport, Kiss et al., 2006 See Rapoport, Herrmann et al., 2006 Country, Setting: Canada, rehabilitation center Enrollment Period: NR Design: Prospective cohort Time from injury, days ± SD: 46.9 ± 34 Length of follow up: 1 year Dep. Scale/Tool: SCID | Inclusion criteria:; - At least 50 yrs old; Exclusion criteria:; - Pre-injury history of neurological disease; - Serious acute medical illness; - Schizophrenia or bipolar disorder; - Drug abuse; TBI Def: Mild TBI: According to ACRM criteria Moderate TBI: GCS score of 9 to 12 and PTA < 1 week, or met criteria for mild TBI but had an intracranial complication of TBI (e.g., contusion) | Group(s): Patients with mild to moderate TBI N screened: NR N eligible: 77 N included: 77 N at conclusion: 46 Depression, n (%): Prior to injury: 14 (18.2) At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: 67.12 ± 8.4 Age ≥16, n (%): 77 (100) Global injury severity (ISS, RTS, etc.): NR Severity of TBI, n (%): Mild: 44 (57.1) Moderate: 33 (42.9) Mechanism/type of injury: NR Area of brain injured: NR Concomitant injuries: NR | Depression: SCID: DSM-IV criteria Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Psychosocial functioning and psychological distress: RHFQ, GHQ Post-concussive symptoms: RPDQ Informant ratings: FAQ | Depression, n (%): Baseline: 12 (15.6) 1-year^*^: 5/9 (55.6) Taking depression medications, 1 year, n (%): Antidepressants: 4/5 (80%) Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: RHFQ, baseline, mean ± SD: MDD: 25.0 ± 7.9 (n=12) No MDD: 10.7 ± 10.9 (n=58) RHFQ, 6 months, mean ± SD: MDD: 26.2 ± 8.5 (n=6) No MDD: 9.9 ± 9.9 (n=38) RHFQ, 1 year, mean ± SD: MDD: 16.3 ± 13.0 (n=8) No MDD: 10.2 ± 11.3 (n=37)
Author: Rapoport et al., 2005 Country, Setting: Canada, tertiary care center Enrollment Period: NR Design: Cross-sectional Time from injury, days ± SD: G1: 214.7 ± 74.1 G2: 194.8 ± 34.8 Length of follow up: NA Dep. Scale/Tool: SCID | Inclusion criteria:; - 65 or younger; - Non-penetrating mild or moderate TBI; Exclusion criteria:; - Premorbid history of focal brain disease (e.g., stroke, tumor); - Serious medical illness (e.g., acute heart or renal failure, malignancy); - History of dementia, schizophrenia or bipolar disorder; TBI Def: Mild TBI: LOC ≤ 30 minutes; after 30 minutes, an initial GCS of 13–15; PTA ≤ 24 hrs (based on ACRM criteria) Moderate TBI: GCS of 9–12 and PTA < 1 week | Group(s): Patients with TBI G1: Patients with major depression G2: Patients without major depression N screened: NR N eligible: NR N included: G1: 21 G2: 53 N at conclusion: NA Depression, n (%): Prior to injury: G1: 5 (23.8) G2: 3 (5.6) At time of injury: NR Other preexisting psychiatric conditions, %: Alcohol misuse: 13.5 Substance misuse: 16.2 N with prior TBI: NR Age, yrs ± SD: G1: 41.4 ± 13.2 G2: 32.3 ± 12.2 Age ≥16, n (%): 74 (100) Global injury severity: NR Severity of TBI, PTA > 24 hrs, n (%): G1: 12 (60) G2: 35 (67.3) | Depression: SCID: DSM-IV criteria Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Cognitive Measures: Wechsler Adult Intelligence Scale: assessed attention/working memory and processing speed Wechsler Memory Scale: assessed logical memory Wisconsin Card Sorting Test: assessed executive functioning | Depression, n (%): Major depression: 21 (28.4) Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Wechsler Adult Intelligence Scale, mean ± SD: Working memory: G1: 22.6 ± 9.1 G2: 30.1 ± 6.4 Processing speed: G1: 14.4 ± 4.6 G2: 18.9 ± 4.9 Wechsler Memory Scale, mean ± SD: G1: 21.8 ± 8.6 G2: 29.8 ± 8.2 Wisconsin Card Sorting Test, mean ± SD: G1: 4.0 ± 2.2 G2: 5.3 ± 1.3
Author: Rapoport et al., 2003 See Rapoport et al., 2003 Country, Setting: Canada, tertiary care center Enrollment Period: NR Design: Cross-sectional Time from injury, days ± SD: 49.0 ± 30.0 Length of follow up: NA Dep. Scale/Tool: SCID | Inclusion criteria:; - Non-penetrating, mild TBI; Exclusion criteria:; - Preinjury history of focal brain disease (e.g., stroke, tumor); - Serious acute medical illness (e.g., heart or renal failure, malignancy); - Previous diagnosis of schizophrenia, bipolar disorder, or dementia; TBI Def: Mild TBI: LOC ≤ 30 min; after 30 mins, an initial GCS of 13–15; PTA ≤ 24 hrs (based on ACRM criteria) | Group(s): G1: Patients with TBI aged 16 to 59 G2: Patients with TBI aged 60 and older N screened: 222 N eligible: 210 N included: G1: 146 G2: 64 N at conclusion: NA Depression, n (%): Prior to injury: G1: 13 (8.9) G2: 16 (25.0) At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI (%): G1: 42 (28.8) G2: 18 (28.1) Age, yrs ± SD: G1: 36.4 ± 11.4 G2: 72.0 ± 8.6 Age ≥16, n (%): 210 (100) Global injury severity: NR Severity of TBI, n(%): Mild: 210 (100) | Depression: SCID: DSM-IV criteria Other co-morbidities: Per MD records, no tests PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric conditions: NR Health related QoL or functional status: MMSE | Depression, n (%): Major Depression: G1: 31/146 (21.2) G2: 4/64 (6.3) G1/G2: P < 0.01 Depression, OR (95% CI): G1/G2: 4.04 (1.4, 12.0) Previous history of MD, patients with MD, n (%): 7/35 (20) Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use, %: Drug: G1: 14.4 G2: 1.6 Alcohol: G1: 11.6 G2: 4.7 Other psychiatric conditions: NR Health related QoL or functional status: MMSE score, mean ± SD: Total: 28.9 ± 1.1 G1: 28.7 ± 1.2 G2: 29.0 ± 1.0 G1/G2: P = 0.069
Author: Rapoport et al., 2003 See Rapoport et al., 2003 Country, Setting: Canada, tertiary care center Enrollment Period: NR Design: Cross-sectional Time from injury, days (range): 48.4 ± 33.6 (1–227) Length of follow up: NR Dep. Scale/Tool: SCID | Inclusion criteria:; - Non-penetrating, mild TBI; Exclusion criteria:; - Preinjury history of focal brain disease (e.g., stroke, tumor); - Serious acute medical illness(e.g., heart or renal failure, malignancy); - Previous diagnosis of schizophrenia, bipolar disorder, dementia, or major depressive disorder; TBI Def: Mild TBI: LOC at time of injury of 30 min or less; after 30 mins, an initial GCS of 13–15; PTA less than 24 hrs (based on ACRM criteria) | Group(s): G1: Patients with depression post-TBI G2: Patients without depression post-TBI N screened: 211 N eligible: 170 N included: G1: 26 G2: 144 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: History of significant alcohol misuse, n (%): G1: 3 (11.5) G2: 10(6.9) History of significant substance misuse, n (%): G1: 3 (11.5) G2: 13 (9) N with prior TBI (%): G1: 6 (23.1) G2: 33 (22.9) Age, yrs ± SD: G1: 41.3 ± 17.8 G2: 44.8 ± 20.5 Total: 44.2 ± 20.1 Age ≥16, n (%): NR Global injury severity: NR | Depression: SCID: DSM-IV criteria Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: Interview and clinician‘s judgment Other psychiatric diagnoses: NR Health related QoL or functional status: GHQ Riverhead Head Injury Follow-up Questionnaire NRS GOS | Depression, n (%): Major depression: 26/170 (15.3) Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder: General Health Questionnaire, anxiety score, mean ± SD: G1: 5.5 ± 2.3 G2: 2.6 ± 2.6 G1/G2: P < 0.0001 Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: Rivermead Post Concussion Disorder Questionnaire score, mean ± SD: G1: 43.4 ± 17.2 G2: 19.9 ± 17.3 G1/G2: P < 0.0001 Health related QoL or functional status: General Health Questionnaire, total score, mean ± SD: G1: 20.2 ± 6.6 G2: 9.6 ± 7.7 G1/G2: P < 0.0001
Author: Rapoport et al., 2002 Country, Setting: Canada, tertiary care centers Enrollment Period: October 1994 to November 1998 (severe TBI); January 1998 to October 2000 (mild and moderate TBI) Design: Cross-sectional Time from injury, days ± SD: G1: 77.95 ± 21.8 G2: 79.66 ± 24.4 G3: 93.80 ± 9.7 Length of follow up: NA Dep. Scale/Tool: NRS-R | Inclusion criteria:; - Abnormal CT scan obtained within 24 hours of injury; - Postresuscitation GCS motor score of 1 5 (total GCS <8); Exclusion criteria:; - Evidence of hypotension (systolic BP < 90 mm Hg for > 30 minutes after resuscitation); - Hypoxia (saturation < 94%) for 30 minutes after resuscitation; - Estimated AIS score > 4 for any organ system; - GCS of 3 with unreactive pupils; - Inability to randomize within 6 hours of injury; - Prior admission for TBI; TBI Def: Mild TBI: LOC for less than 20 minutes, a GCS of 13 or above, and PTA for less than 24 hours (based on ACRM criteria) Moderate TBI: GCS of 9–12 or a GCS of ≥ 13 with intracerebral complication on CT scan Severe TBI: NR | Group(s): G1: Patients with mild TBI G2: Patients with moderate TBI G3: Patients with severe TBI N screened: 870 N eligible: 323 N included: G1: 102 G2: 41 G3: 139 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: G1: 32.3 ± 11.8 G2: 32.3 ± 12.5 G3: 31.9 ± 10.6 Age ≥16, n (%): NR Global injury severity, ISS score, mean ± SD: G1: 15.4 ± 10.3 (n=83) G2: 17.4 ± 9.8 (n=34) G3: 25.6 ± 7.4 | Depression: NRS-R: classified as not present, mild, moderate, or severe Other co-morbidities: PTSD: NR Other anxiety disorder: NRS-R Irritability: NRS-R Aggression: NR Suicidality: NR Substance use: NR Other psychiatricdiagnoses: NR Health related QoL or functional status: GOS: severe disability, moderate disability, good recovery | Depression, %: Severe: G1: 0 G2: 0 G3: 0.7 Moderate: G1: 9.8 G2: 17.1 G3: 11.5 Mild: G1: 22.5 G2: 22.0 G3: 36.7 Not present: G1: 64.7 G2: 61.0 G3: 51.1 Taking depression medications: NR Other co-morbidities, %: PTSD: NR Other anxiety disorder: Severe G1: 2.0 G2: 0 G3: 0.7 Moderate G1: 9.8 G2: 22.0 G3: 10.1 Mild G1: 35.3 G2: 19.5 G3: 45.3 Not present G1: 52.9 G2: 58.5 G3: 43.9
Author: Rowland et al., 2005 Country, Setting: US, rehabilitation centers Enrollment Period: NR Design: Cross-sectional Time from injury, days ± SD (range): 57.3 ± 37.8 (8–148) Length of follow up: NA Dep. Scale/Tool: BDI-II | Inclusion criteria: See exclusion criteriaExclusion criteria:; - Cognitive or motor abnormalities that precluded the ability to give informed consent or complete standard administrations of the neuropsychological tests; - Self-report of previous brain injury or documentation of previous TBI in medical records; TBI Def: Documented by neuroradiologic scans (e.g., MRI, CT) or indisputable independent evidence (e.g., paramedics at the scene or emergency room personnel observation and documentation of loss of consciousness due to traumatic impact) TBI Severity determined by several cut-offs: time to follow commands (24 hours), length of PTA (24 hours), and duration of coma (6 hours) | Group(s): Patients with TBI N screened: NR N eligible: NR N included: 51 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: None (see exclusion criteria) Age, yrs ± SD (range): 40.3 ± 16.0 (18–70) Age ≥16, n (%): 51 (100) Global injury severity: NR Severity of TBI, n (%): Severe: 26 (51) Mild-moderate: 25 (49) Mechanism/type of injury, n (%): Car accident: 23 (45.1) Fall: 14 (27.5) Assault: 9 (17.6) Other: 5 (9.8) | Depression: BDI-II ≥ 14 was classified as depressed (severity of depression not identified in this study) BDI-II analyzed to extract factors based on cumulative percent variance: Negative Self Evaluation: measures level ofperson‘s perception and cognitive view of self Symptoms of Depression: measures symptoms largely associated with DSMV-IV criteria for MDE Vegetative Symptoms of Depression: symptoms associated with depression, but failed to load under same factor as depression Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR | Depression, BDI-II, n (%): Depressed: 13 (25.5)^*^ Total variance for each factor, %: Negative Self Evaluation: 20 Symptoms of Depression: 18^*^ Vegetative Symptoms of Depression: 12 Taking depression medications: NR Other co-morbidities, n (%): PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: 13 (25.5) Other psychiatric diagnoses: NR Health related QoL or functional status: NR
Author: Ruocco et al., 2007 Country, Setting: US, other Enrollment Period: NR Design: Cross-sectional Time from injury: NR Length of follow up: NA Dep. Scale/Tool: MCMI-III | Inclusion criteria:; - At least 18 yrs of age; - Referred for neuropsychological evaluation in relation to head trauma; - Completion of the MCMI-III as part of a larger neuropsychological battery; Exclusion criteria:; - Suspected dementia (G2); TBI Def: According to ACRM criteria | Group(s): G1: Patients with TBI G2: Psychiatric patients N screened: NR N eligible: NR N included: G1: 231 G2: 231 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: G1: 40.6 ± 12.4 G2: 40.9 ± 12.1 Age ≥16, n (%): 462 (100) Global injury severity: NR Severity of TBI, %: Mild: G1: 84.0 Moderate: G1: 16.0 Reported LOC: G1: 43.9 | Depression: MCMI-III: Base Rate (BR) scores ≥ 75 was used to demark scale elevations that are clinically significant and determine if there were any differences between the TBI sample and the matched group of psychiatric patients. Other co-morbidities: PTSD: MCMI-III Other anxiety disorder: MCMI-III Irritability: NR Aggression: MCMI-III Suicidality: NR Substance use: MCMI-III Other psychiatric diagnoses: MCMI-III Health related QoL or functional status: NR | Depression, n (%): Major depression: G1: 70 (30.3) G2: 68 (29.4) Depressive G1: 39 (16.9) G2: 96 (41.6) Taking depression medications: NR Other co-morbidities, n (%): PTSD: G1: 52 (22.5) Other anxiety disorder: G1: 32 (57.1) Irritability: NR Aggression: Aggressive (sadistic): G1: 6 (2.6) Suicidality: NR Substance use: Alcohol dependence: G1: 3 (1.3) Drug dependence: G1: 5 (2.2) Other psychiatric diagnoses: Schizoid: G1: 57 (24.7) Avoidant: G1: 63 (27.3) Dependent: G1: 71 (39.7) Histrionic: G1: 37(16.0) Narcissistic: G1: 35 (15.2) Antisocial: G1: 10 (4.3) Compulsive: G1: 47 (29.3)
Author: Satz, Zaucha et al., 1998 Satz, Forney et al., 1998^ See McCleary et al., 1998 Country, Setting: US, academic medical centers Enrollment Period: 1991 to 1995 Design: Cross-sectional Time from injury: Up to 6 months Length of follow up: NA Dep. Scale/Tool: SCL-90-R, NRS-13 | Inclusion criteria:; - At least 16 yrs of age; - Initial GCS score ≤12, or initial GCS score of ≥ 13 with abnormalities on admission CT scan; - Literate and able to understand either Spanish or English; - Bodily injuries other than to the head, admitted to the hospital for 24 hours or more, and AIS severity level comparable to the TBI patients (G2); Exclusion criteria:; - Less than 6 mos postinjury; - Too injured to complete neuropsychological assessments; - Severe pre-existing comorbidity, such as chronic heart failure, stroke, chronic severe neurological disease (e.g., Parkinson‘s disease, AIDS dementia, presenile dementia), or previous severe diminished mental capacity; TBI Def: NR^†^ | Group(s): G1: TBI patients with severe disability G2: TBI patients with moderate disability G3: TBI patients with good recovery G4: Other injury comparison group Ga: Depressed (SCL-90-R criteria) patients in G1+G2 Gb: Nondepressed patients in G1+G2 Gc: Nondepressed patients in G3+G4 N screened: NR N eligible: NR N included: G1: 21 G2: 42 G2^: 43 G3: 37 G3^: 36 G4: 30 Ga^: 17 Gb^: 47 Gc^: 64 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR | Depression: SCL-90-R: a deviation score of greater than 2 standard deviations adjusted for gender indicates major depression NRS-13: a score greater than 4 indicates moderate to severe depression Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: GOS: standard definitions | Depression, SCL-90-R, % G1: 24 G2: 28 G3: 2.7 G4: 3.3 Depression, NRS-13, %: G1: 52 G2: 35 G3: 22 G4: 17 Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status:^*^ AIMS score, mean ± SD: Ga: 59.1 ± 8.4 Gb: 42.5 ± 10.7 Gc: 39.2 ± 12.1
Author: Schofield et al., 2006 Country, Setting: Australia, other Enrollment Period: September 2003 to June 2004 Design: Cross-sectional Time from injury: NR Length of follow up: NR Dep. Scale/Tool: RDS | Inclusion criteria:; - Inmates recruited consecutively or chosen randomly based on prison ID number on days with too many potential new participants to be interviewed; Exclusion criteria: See inclusion criteria TBI Def: Self-report of a blow to the head the causing the participant to become dazed and confused without LOC (TBI without LOC) or unconscious or blacked-out (TBI with LOC) Mild TBI: LOC < 30 minutes | Group(s): Inmates examined for TBI history G1: No TBI‘s G2: 1 to 3 TBI‘s G3: ≥ 4 TBI‘s N screened: NR N eligible: NR N included: G1: 36 G2: 79 G3: 85 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: 30.6 ± 8.1 Age ≥16, n (%): 200 (100) Global injury severity: NR Severity of TBI, n: TBI with LOC ≥ 30 minutes: 53 TBI with LOC <30 minutes: 77 TBI without LOC: 34 Mechanism/type of injury: NR | Depression: RDS: score of one or more indicated positive result for lifetime history of major depressive disorder Other co-morbidities: PTSD:NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: Suicide or self-harm – direct inquiry Substance use: AUDIT score of 8 or more Specific enquiry for illegal drug use in the past 4 weeks Other psychiatric diagnoses: Psychosis: screener from the Australian Low Prevalence Disorders Study: weighted scores of four or more = positive (current or past) ICD personality international personality disorder screener: 3 or more items from either scales for impulsive or dissocial personality | Depression: Depression associated with TBI and increased as number of TBI‘s increased: Depression, n (%): G1: 3 (10) G2: 14 (19) G3: 26 (31) Depression, OR (95% CI): G2+G3/G1: 3.6 (1.0, 12.8) G2/G1: 2.5 (0.6,9.6) G3/G1: 4.7(1.3, 17.5) Taking depression medications (%): NR Other co-morbidities: PTSD:NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: Suicide or self-harm, n (%): G1: 4 (13) G2: 11 (14) G3: 21 (25) Suicide or self-harm, OR (95% CI): G2+G3/G1: 1.7 (0.6, 5.3) G2/G1: 1.1 (0.3, 4.0) G3/G1: 2.4 (0.7, 7.6)
Author: Sebit et al., 1998 Country, Setting: Kenya, tertiary care center Enrollment Period: 1991 to 1992 Design: Cross-sectional Time from injury: 6 to 8 months Length of follow up: NA Dep. Scale/Tool: CIS-R, DSM-III-R | Inclusion criteria:; - 16 to 65 yrs old; - Non-penetrating, closed head injury (CHI); Exclusion criteria:; - Previous hospital admission due to LOC, associated fractures elsewhere in the body, or undergone major surgical interventions (i.e. elevation of depressed skull fracture) for the fractured lower limb injury group (G2); TBI Def^*^: Mild CHI: Consciousness on admission and throughout the period of hospitalization and absence of neurologic deficits Moderate CHI: Comatose for not more than 24 hrs with possible neurologic deficits Severe CHI: Duration of coma exceeding 24 hours and may have manifested focal neurologic deficits. | Group(s): G1: Patients with CHI G2: Patients with FLLI N screened: NR N eligible: 100 N included: G1: 37 G2: 39 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: G1: 32.2 ± 9.1 G2: 30.5 ± 7.9 Age ≥16, n (%): 100 (100) Global injury severity: NR Severity of TBI, %: Mild: G1: 59.5 Moderate: G1: 21.6 Severe: G1: 18.6 | Depression: CIS-R: cutoff for cases of 13 points then correlated with DSM-III-R criteria Other co-morbidities: PTSD: NR Other anxiety disorder: CIS-R cutoff for cases of 13 points then correlated with DSM-III-R criteria Irritability: NR Aggression: NR Suicidality: NR Substance use: WHO Audit Core and an 8 item procedure for alcohol abuse with a cutoff of 8 points Other psychiatric diagnoses: Psychiatric interview for delusional disorders using DSM-III-R criteria Health related QoL or functional status: NR | Depression, n (%): G1: 20 (54.1) G2: 10 (25.6) Taking depression medications: NR Other co-morbidities, n (%): PTSD: NR Other anxiety disorder: G1: 8 (21.6) G2: 6 (15.4) Irritability: NR Aggression: NR Suicidality: NR Substance use: G1: 2 (5.4) G2: 1 (2.6) Other psychiatric diagnoses: Delusional disorder: G1: 0 G2: 3 (7.7) Health related QoL or functional status: NR
Author: Seel and Kreutzer, 2003 See Seel et al., 2003 Country, Setting: US, rehabilitation center Enrollment Period: 1996 to 2000 Design: Cross-sectional Time from injury, mos ± SD (range): 27.8 ± 43.8 (1–323) Length of follow up: NA Dep. Scale/Tool:, BDI, NFI-D | Inclusion criteria:; - Completion of comprehensive evaluations at an outpatient rehabilitation center between 1996 and 2000; Exclusion criteria: See inclusion criteria TBI Def: NR^*^ | Group(s): Patients with TBI N screened: NR N eligible: NR N included: 172 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: 36.5 ± 12.2 Age ≥16, n (%): 172 (100) Global injury severity: NR Severity of TBI, GCS score, mean: 10.51 Mechanism/type of injury, %: MVA: 68 Violence: 13 Falls: 12 Area of brain injured: NR Concomitant injuries: NR | Depression: BDI ≥ 21 NFI ≥ 43 Other co-morbidities: PTSD: NR Other anxietydisorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, BDI, %: Extreme: 2 Severe: 12 Moderate: 24 BDI score, mean ± SD: 16.9 ± 11.4 Depression, NFI, %: 30 NFI score, mean ± SD: 36.1 ± 11.6 Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR
Author: Seel et al., 2003 See Seel and Kreutzer, 2003 Country, Setting: US, rehabilitation centers Enrollment Period: NR Design: Cross-sectional Time from injury, mos ± SD: 35.3 ± 26.9 Length of follow up: NA Dep. Scale/Tool: NFI-R, DSM-IV | Inclusion criteria:; - Completion of a TBIMS outpatient follow-up evaluation between 1996 and 2000; - Availability of demographic data; - Completion of the NFI at annual follow-up intervals; Exclusion criteria: See inclusion criteria TBI Def: Damage to brain tissue caused by an external mechanical force as evidenced by medically documented LOC or PTA due to brain trauma or by objective neurological findings that can be reasonably attributed to TBI on physical examination or mental status examination | Group(s): Patients with TBI G1: Depressed patients G2: Non-depressed patients N screened: NR N eligible: NR N included: Total: 666 G1: NR G2: NR N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: 38.0 ± 14.5 Age ≥16, n (%): 666 (100) Global injury severity: Acute treatment, days ± SD: 21.2 ± 16.7 Inpatient rehabilitation, days ± SD: 33.7 ± 25.6 | Depression: Measured using NFI to screen for DSM-IV major depression symptoms. NFI comprised of 70 items measures neurobehavioral problems in TBI patients – contains 6 domains (depression, somatic, memory/attention, communication, aggression, & motor) Respondents responses measured on 5 point Likert scale DSM-IV criteria used to classify depressive symptoms of NFI scale Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, DSM-IV criteria, %: MDE: 27 Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: Threaten to hurt self, %: Total: 7 G1: 19 G2: 3 Substance use: NR Other psychiatric diagnoses:^*^ NFI criteria, mood symptoms, always/ often, % : Easily angered: 26 Frustrated: 25 Sad, blue: 18 Feel hopeless: Total:12 G1: 38 G2: 3 Argue: 16 Curse at others: 12 Scream or yell: 9 Hit or push others: 2 Bored: 22 Sit with nothing to do: 19 Lonely: 19 Loss of interest in sex: 16
Author: Sherer et al., 2007 Country, Setting: US, rehabilitation center Enrollment Period: February 2003 to August 2005 Design: Prospective cohort Time from injury, days (range): 82 (23–938) Length of follow up: NA Dep. Scale/Tool: CES-D | Inclusion criteria:; - All patients admitted to rehabilitation center and a family member/ significant other; - Ability to provide informed consent; Exclusion criteria: See inclusion criteria TBI Def: NR^*^ | Group(s): Patients with TBI N screened: 94 N eligible: 94 N included: 69 N at conclusion: 49 Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: 29.3 ± 13.2 Age ≥16, n (%): NR Global injury severity, acute length of stay, mean ± SD: 23.1 ± 16.2 Severity of TBI, GCS score, mean ± SD: 8.0 ± 3.7 Mechanism/type of injury, n (%): MVC: 54 (78.2) Fall: 6 (8.7) Assault: 5 (7.2) Other: 3 (4.3) Area of brain injured: NR | Depression: CES-D: NR Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: California Psychotherapy Alliance Scale (CALPAS) Prigatano Alliance Scale (PAS) Awareness Questionnaire (AQ) Disability Rating Scale (DRS) Productivity Status | Depression, n (%): Severe: 3 (4.3) Moderate: 6 (8.7) Mild: 13 (18.8) CES-D score, mean ± SD: 11.6 ± 8.0 Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: CALPAS score, mean ± SD: 122.0 (16.5) CALPAS, family member, mean ± SD: 126.2 (10.3) CALPAS score, clinician, mean ± SD: clinician: 112.0(14.4) PAS score, mean ± SD: 11.3 ± (1.1) AQ score, mean ± SD: 49.4 ± 9.1
Author: Sherman et al., 2000 Country, Setting: Canada, other Enrollment Period: NR Design: Cross-sectional Time from injury, yrs ± SD: 2.5 ± 2.0 Length of follow up: NA Dep. Scale/Tool: MMPI-2 | Inclusion criteria:; - Availability of information on head injury severity; - Complete neuropsychological test data including MMPI-2; - No evidence of symptom exaggeration (i.e. below-chance performance) on a forced-choice symptom validity measure (Victoria Symptom Validity Test); Exclusion criteria: See inclusion criteria TBI Def: Mild HI: LOC of < 1 hour and PTA of < 24 hours (based on ACRM criteria) Moderate-to-severe HI: LOC > 1 hour and PTA > 24 hours | Group(s): G1: Mild TBI G2: Moderate-to-severe TBI Ga: Low Dep score Gb: High Dep score N screened: NR N eligible: 175 N included: G1: 114 G2: 61 Ga: 117 Gb: 58 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: 32.8 ± 12.7 Age ≥16, n (%): NR Global injury severity: NR Severity of TBI, n(%): Mild TBI: 114 (65) Moderate/Severe TBI: 61 (35) | Depression: Measured by Depression content scale (Dep) of MMPI-2 High Dep score (T-score > 65) includes all individuals with symptoms in the clinical range Low Dep score (T- score < 65) includes all individuals with symptoms not in clinical range Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: NR | Depression, high score, n (%)^*^: Total: 58 (33) Mild TBI: 36 (32) Moderate/Severe TBI: 22 (36) Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Logical memory, test scores in impaired range, %: Ga: 19.2 Gb: 32.8 Ga/Gb: P = 0.04 PASAT memory, test scores in impaired range, %: Ga: 25.5 Gb: 41.9 Ga/Gb: P = 0.10
Author: Slaughter et al., 2003 Country, Setting: US, other Enrollment Period: NR Design: Cross-sectional Time from injury: NR Length of follow up: NA Dep. Scale/Tool: PRIME-MD | Inclusion criteria:; - 18 years of age or older; - English speaking; - Completely sentenced on all current charges (no further pending legal charges); Exclusion criteria: See inclusion criteria TBI Def: Mild TBI:^*^ A head injury immediately followed by LOC ≤ 30 minutes, alteration of mental status at the time of the accident (e.g. feeling dazed, confused or disoriented), or loss of memory of the time around the injury (based on ACRM criteria) Moderate/severe TBI:^*^ Any injury of greater severity than mild TBI | Group(s): G1: Inmates with self-reported TBI G2: Inmates without self-reported TBI N screened: 475 N eligible: 91 N included: G1: 25 G2: 25 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, n (%): 18–29: 30 (43.5) 30–39: 20 (49.0) 40–49: 17 (24.6) 50–59: 2 (2.9) Age ≥16, N (%): 69 (100) Global injury severity (ISS, RTS, etc.): NR Severity of TBI, n: Mild: G1: 20 Moderate/severe: G1: 5 Mechanism/type of injury: NR | Depression: PRIME-MD: NR Other co-morbidities: PTSD: NR Other anxiety disorder: PRIME-MD Irritability: NR Aggression: Brief Anger and Aggression Questionnaire (BAAQ) Suicidality: NR Substance use: PRIME-MD Other psychiatric diagnoses: BAAQ, COWAT, WAIS-R Vocabulary, WAIS-R Picture Completion, Trail Making Test A and B, WMS-R Health related QoL or functional status: BAAQ, COWAT, WAIS-R Vocabulary, WAIS-R Picture Completion, Trail Making Test A and B, WMS-R | Depression, n (%): MDD: G1: 13 (52) G2: 9 (36) MDD in partial remission: G1: 1 (4) G2: 1 (4) Dysthymia: G1:10 (40) G2: 8 (32) Minor depressive disorder: G1: 2 (8) G2: 3 (12) Taking depression medications (%): NR Other co-morbidities: PTSD: NR Other anxiety disorder: Generalized anxiety disorder, n (%): G1: 10 (40) G2: 7 (28) Anxiety disorder NOS, n (%): G1: 3 (12) G2: 2 (8) Irritability: NR Aggression: BAAQ score, mean ± SD: G1: 11.6 G2: 7.8 G1/G2: P = 0.05 Suicidality: NR Substance use: Probable alcohol abuse/dependence, n (%): G1: 14 (56) G2: 13 (52)
Author: Sliwinski et al., 1998 See Hibbard et al., 1998; Gordon, Brown et al., 1998; Gordon, Sliwinski et al., 1998 Country, Setting: US, other Enrollment Period: NR Design: Cross-sectional Time from injury, mean yrs: 7.6 Length of follow up: NR Dep. Scale/Tool: SCID, BDI | Inclusion criteria:; - 18 years of age or older at the time of injury; - Brain injury of traumatic origin occurring at least 1 year prior to the study; - Current age < 65 years; - Self-identified as having received a TBI and as having a disability; - Able to engage in a 3 to 4-hour interview; - Resident of New York state and living in non-institutional settings in the community; Exclusion criteria: See inclusion criteria TBI Def: Self-report | Group(s): Patients with TBI N screened: 433 N eligible: 100 N included: 100 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, assessment, yrs ± SD:^*^ 39.8 ± 10.2 Age, time of injury, mean (range): 32 (18–59) Age ≥16, n (%): 100 (100) Global injury severity: NR Severity of TBI, LOC, %: Dazed/confused < 20 minutes: 20 > 20 min to < 1 day: 9 > 1 day to < 1 week: 20 1–4 weeks: 17 > 1 month: 24 | Depression: SICD: DSM-IV criteria BDI: NR Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: TIRR | Depression, SCID, n (%): MDD: 23 (23) Dysthymia: 2 (2) BDI score and SCID diagnosis of depression, correlation: 0.30 (P < 0.05) Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: BDI score and TIRR Symptom Checklist score, correlation: 0.67 (P < 0.05)
Author: Stalnacke, 2007 Country, Setting: Sweden, tertiary care center Enrollment Period: 2001 Design: Cross-sectional Time from injury: 3 years Length of follow up: NA Dep. Scale/Tool: BDI | Inclusion criteria:; - Admitted to the ED within 24 hours after the trauma; - GCS 13 to 15 on arrival to the ED; - Diagnosis of concussion/commotion cerebri/mild head injury/mild TBI resulting in hospitalization for observation; Exclusion criteria: See inclusion criteria TBI Def: Mild TBI: GCS 13 to 15 | Group(s): Patients with mild TBI N screened: 214 N eligible: 201 N included: 163 N at conclusion: NA Depression, n (%): Prior to injury: 7 (4.3) At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI (%): 68 (42) Age, yrs ± SD: 30.6 ± 14.4 Age ≥16, n (%): 163 (100) Global injury severity: NR Severity of TBI, n (%): Mild TBI: 163 (100) PTA, minutes ± SD (range): 41 ± 118 (0–720) LOC, minutes ± SD (range): 4.0 ± 7 (0–30) | Depression: BDI: 0–9: Asymptomatic 10–18: Mild to moderate depression 19–29: Moderate to severe depression 30–63: Extremely severe depression Other co-morbidities: PTSD: IES Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: CIQ LiSat-11 RPQ | Depression, %: Mild to moderate depression: 25.0 Moderate to severe depression: 15.0 BDI score, mean ± SD: 6.9 ± 8.1 Taking depression medications: NR Other co-morbidities: PTSD: IES score, mean ± SD: 9.6 ± 13.0 Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: CIQ score, mean ± SD: 20.2 ± 4.2 LiSat-11 score, mean ± SD: 46.4 ± 10.7 RPQ score, mean ± SD: 10.7 ± 13.2
Author: Tateno et al., 2004 See Tateno et al., 2003; Jorge et al., 2004 Country, Setting: US, tertiary care centers Enrollment Period: NR Design: Cross-sectional Time from injury, days ± SD: NR Length of follow up: NA Dep. Scale/Tool: SCID, HAM-D | Inclusion criteria: See exclusion criteria Exclusion criteria:; - Penetrating head injury or spinal cord injury; - Severe comprehension deficits that precluded thorough neuropsychiatric evaluation; TBI Def: Mild TBI: GCS score 13 to 15 Moderate TBI: GCS score from 9 to 12, or a GCS score of 12 to 15 with intracranial surgical procedures or with focal lesions greater than 15 cc Severe TBI: GCS score from 4 to 8 | Group(s): Patients with TBI N screened: NR N eligible: NR N included: 92 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions, n (%): Mood disorder: 23 (25.0) Anxiety disorder: 11 (11.9) Alcohol abuse: 18 (19.6) Drug abuse: 11 (11.9) N with prior TBI: NR Age, yrs ± SD: PLC: 30.4 ± 11.5 (n=10) No PLC: 36.9 ± 16.0 (n=82) Age ≥16: NR Global injury severity: NR 51 (55.4) | Depression: SCID: DSM-IV criteria HAM-D: NR Other co-morbidities: PTSD: NR Other anxiety disorder: HAM-A Irritability: NR Aggression: Overt Aggression Scale (OAS) Suicidality: NR Substance use: NR Other psychiatric conditions: Pathological Laughter and Crying (PLC) Scale Health related QoL or functional status: FIM | Depression, SCID, %: MDD: 21 (22.8) Minor depression: 8 (8.7) Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder, n (%): 36 (39.1) GAD: 20 (21.7) Irritability: NR Aggression: OAS score, mean ± SD: 1.6 ± 3.0 Suicidality: NR Substance use: NR Other psychiatric diagnoses n (%): PLC: 10 (10.9) Depression and PLC: 5 (5.4)^*^ Health related QoL or functional status: FIM, mean ± SD: 61.2 ± SD: 9.8
Author: Tateno et al., 2003 See Jorge et al., 2004; Tateno et al., 2004 Country, Setting: US, tertiary care centers Enrollment Period: NR Design: Cross-sectional Time from injury, days ± SD: G1a: 23.9 ± 17.7 G1b: 33.4 ± 26.5 Length of follow up: NA Dep. Scale/Tool: SCID, HAM-D | Inclusion criteria: See exclusion criteria Exclusion criteria:; - Penetrating head injury or spinal cord injury; - Severe comprehension deficits that precluded thorough neuropsychiatric evaluation; TBI Def: Closed head injury followed by PTA ≥ 30 mins Mild TBI: GCS score 13 to 15 Moderate TBI: GCS score from 9 to 12, or a GCS score of 12 to 15 with intracranial surgical procedures or with focal lesions greater than 15 cc Severe TBI: GCS score from 4 to 8 | Group(s): G1: Patients with TBI G1a: Patients with TBI and significant aggression G1b: Patients with TBI but not significant aggression G2: Multiple trauma patients with no HI or spinal cord injury N screened: NR N eligible: NR N included: G1: 89 G1a: 30 G1b: 59 G2: 26 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions, n (%): Mood disorder: G1: 23 (26.4) G1a: 13 (43.3) G1b: 10 (17.5) G2: 8 (34.8) Anxiety disorder: G1: 11 (12.6) G1a: 4 (13.3) G1b: 7 (12.3) G2: 2 (8.7) Aggressive behavior (post-traumatic): G1: 30 (33.7) G2: 3 (11.5) | Depression: SCID: DSM-III-R criteria HAM-D: NR Other co-morbidities: PTSD: NR Other anxiety disorder: HAM-A Irritability: NR Aggression: Overt Aggression Scale (OAS) ≥ 3 and ≥ 4 episodes of aggressive behavior Suicidality: NR Substance use: NR Other psychiatric conditions: NR Health related QoL or functional status: FIM | Depression, SCID, %: MDD: G1a: 56.7 G1b: 28.8 Minor depression: G1a: 23.3 G1b: 27.1 HAM-D score, mean ± SD: G1a: 12.2 ± 6.4 G1b: 7.6 ± 5.6 G1a/G1b: P < 0.01 Taking depression medications: NR Other co-morbidities: PTSD: NR Other anxiety disorder: HAM-A score, mean ± SD: G1a: 12.8 ± 6.6 G1b: 8.4 ± 5.4 G1a/G1b: P < 0.01 Irritability: NR Aggression, n (%): G1: 30/89 (34) Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: G1: 62.7 ± 10.1 G1a: 63.2 ± 9.7 G1b: 62.5 ± 10.4 G2: 59.4 ± 10.9
Author: Varney et al., 1987 Country, Setting: US, tertiary care centers Enrollment Period: NR Design: Cross-sectional Time from injury, mean yrs (range): 3.4 (2–8) Length of follow up: NA Dep. Scale/Tool: DSM-III | Inclusion criteria:; - History of closed head injury; - Period of un-consciousness lasting from a few minutes to eight days; - At least two yrs postinjury; Exclusion criteria:; - History of head injury (G2); TBI Def: NR | Group(s): G1: Patients with TBI G2: Patients with back injury N screened: NR N eligible: NR N included: G1: 120 G2: 60 N at conclusion: G1: 120 G2: 60 Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: G1: NR G2: None (see exclusion criteria) Age: NR Age ≥16: NR Global injury severity: NR Severity of TBI: NR Mechanism/type of injury: NR | Depression: DSM-III criteria Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: DSM-III Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: DSM-III Health related QoL or functional status: NR | Depression, n (%): MDD: G1: 92/120 (76.7) G2: 23/60 (38.3) MDD onset, n: Immediately or shortly after TBI: G1: 45/92 (48.9) At least six months post TBI: G1: 42/92 (45.7) Taking depression medications (%): NR Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability, n (%): Patient report: G1: 29/92 (31.5) G2: NR Relative report: G1: 80/92 (87.0) G2: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses, n (%): Bipolar: G1: 4/120 (3.3) G2: 0 Schizophrenic: G1: 1/120 (0.8) G2: 0 Health related QoL or functional status: NR
Author: Vasterling et al., 2000 Country, Setting: US, tertiary care center Enrollment Period: NR Design: Cross-sectional Time from injury: NR Length of follow up: NA Dep. Scale/Tool: SCID, BDI | Inclusion criteria:; - Military veterans with exposure to combat as verified by military records; - Completion of the SCID, BDI, Mississippi Scale for Combat-related PTSD, CES, and self report measures of depression, PTSD symptommatology, and combat exposure; Exclusion criteria: See inclusion criteria TBI Def: HI: Injuries to the head from blunt or penetrating force sufficient to cause intracranial injury | Group(s): G1: Veterans with HI G2: Veterans with no HI N screened: 260 N eligible: 171 N included: G1: 87 G2: 84 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: 48.3 ± 9.0 Age ≥16, n (%): 171 (100) Global injury severity: NR Severity of TBI, n: LOC: 56 Data missing: 5 Mechanism/type of injury: NR Area of brain injured: NR Concomitant injuries: NR | Depression: SCID: DSM-IV criteria BDI: 0: None, 59: Severe Other co-morbidities: PTSD: SCID Mississippi Scale score Other anxiety disorder: SCID Irritability: NR Aggression: NR Suicidality: NR Substance use: SCID Other psychiatric diagnoses: SCID Health related QoL or functional status: NR | Depression, n (%): Lifetime:^*^ G1: 61 (70.0) G2: 61 (72.6) Current: G1: 58 (66.7) G2: 48 (57.1) BDI score, mean ± SD: G1: 31.8 ± 11.4 G2: 27.1 ± 12.3 G1/G2: P < 0.05 Taking depression medications: NR Other co-morbidities: PTSD, n (%): Lifetime:^*^ G1: 78 (89.7) G2: 73 (86.9) Current: G1: 76 (87.4%) G2: 72 (85.7%) Mississippi Scale score (PTSD), mean ± SD: G1: 126.0 ± 22.3 G2: 120.2 ± 27.4 Other anxiety disorder, n (%): Lifetime:^*^ G1: 20 (23.0) G2: 18 (21.4) Current: G1: 22 (25.3) G2: 18 (21.4) Irritability: NR Aggression: NR Suicidality: NR
Author: Wade et al., 1998 Country, Setting: UK, rehabilitation center Enrollment Period: NR Design: Cross-sectional Time from injury: 6 months Length of follow up: NA Dep. Scale/Tool: HADS | Inclusion criteria:; - Age 16–65 years; - Reside in Oxfordshire; - Admitted to hospital with head injury of any severity, with or without other injuries; Exclusion criteria:; - Minor head injuries, not requiring admission; TBI Def: Head injury defined as “any blow to the head causing a clinical diagnosis of head injury to be made” Mild: PTA < 1 hr Moderate: PTA ≥ 1 hr but < 24 hrs Severe: PTA ≥ 24 hrs but ≤ 7 days Very severe: PTA > 7 days | Group(s): G1: OXHIS G2: Usual care N screened: 321 N eligible: G1: 184 G2: 130 N included: G1: 181 G2: 122 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI: NR Age, yrs ± SD: G1: 33.5 ± 14.0 G2: 32.5 ± 12.2 Age ≥16, n (%): 303 (100) Global injury severity: NR Severity of TBI, n (%): Very severe: G1: 10 (8) G2: 7 (9) Severe: G1: 21 (18) G2: 17 (22) | Depression: HADS: NR Other co-morbidities: PTSD: NR Other anxiety disorder: NR Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: RHFUQ 0 1–10 11–20 21–30 31–40 | Depression, n (%): Feeling depressed: G1: 33 (25) G2: 29 (34) Taking depression medications: NR Other co-morbidities, n (%): PTSD: NR Other anxiety disorder: NR Irritability: G1: 38 (29) G2: 36 (42) Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Some disability at follow up, %: 61 RHFUQ score, mean ± SD: G1: 5.4 ± 7.8 G2: 8.2 ± 8.8
Author: Whelan-Goodinson et al., 2008 Whelan-Goodinson et al., 2009^ Country, Setting: Australia, tertiary care center Enrollment Period: July 2000 to July 2005 Design: Cross-sectional Time from injury, yrs ± SD (range): 2.98 ± 1.47 (0.5–5.5) Length of follow up: NA Dep. Scale/Tool: SCID, HADS^ | Inclusion criteria:; - 17 to 70 years of age at time of injury; - Lowest recorded GCS score < 15; - Cognitive capacity for participation as determined by neuropsychologist; - Proficient in English; - No history of TBI or neurological disorders; Exclusion criteria: See inclusion criteria TBI Def: NR^*^ | Group(s): Patients with TBI N screened: 720 N eligible: 550 N included: 100 N at conclusion: NA Depression, n (%): Prior to injury: 17 (17) At time of injury: NR Other preexisting psychiatric conditions, n (%): Anxiety disorder: 13 (13) Substance abuse disorder: 41 (41) N with prior TBI: 0 (see inclusion criteria) Age, yrs ± SD: 37.18 ± 14.19 Age ≥16, n (%): Total: 100 (100) Global injury severity : Length inpatient stay, days: 41.59 Severity of TBI^: Lowest pre-intubation GCS score, mean ± SD: 9.1 ± 4.12 GCS, %: 13–14: 35 9–12: 20 3–8: 45 | Depression: SCID: DSM-IV criteria HADS^: 7 item depression subscale, 4 pt scale per answer (0–3) 0–7: Normal 8–10: Mild 11–14: Moderate 15:21 Severe Other co-morbidities: PTSD: NR Other anxiety disorder: SCID Irritability: NR Aggression: NR Suicidality: NR Substance use: AUDIT, DAST Other psychiatric diagnoses: SCID Health related QoL or functional status: SPRS | Depression, n (%): Major depression: 32 (32) Non-major depression:2 (2) Resolved post-TBI depression: 12 (12) Severity, n (%)^: Mild: 9 (26.5) Moderate: 12 (35.3) Severe: 13 (38.2) 13/34 (38.2) patients diagnosed with SCID depression were in the “normal” HADS range 5/66 (7.6) patients without SICD diagnosed depression scored in the clinical range on the HADS; none scored above 12 Taking depression medications: NR Other co-morbidities, n (%): PTSD: 11 (11) Other anxiety disorder: GAD: 14 (14) 36 (36)^ Depressed patients with comorbid anxiety, %: 73.5^ Irritability: NR Aggression: NR Suicidality: NR Substance use: Current use: 17 (17) Resolved use: 4 (4)
Author: Ziino and Ponsford, 2006 Country, Setting: Australia, rehabilitation center Enrollment Period: NR Design: Cross-sectional Time from injury, days ± SD (range): G1: 240.3 ± 222.7 (21 to 1,153) G2: NA Length of follow up: NA Dep. Scale/Tool: HADS | Inclusion criteria:; - 16 to 60 years old; - Adequate physical and cognitive abilities and understanding of English to complete tasks; - No history of previous neurological disturbance; - Not using illicit drugs; - Comparison group had no history of brain injury or neurological illness; Exclusion criteria: See inclusion criteria TBI Def: NR^*^ | Group(s): G1: Participants with TBI G2: Comparison group (no TBI) N screened: NR N eligible: G1: 49 G2: NR N included: G1: 46 G2: 46 N at conclusion: NA Depression: Prior to injury: NR At time of injury: NR Other preexisting psychiatric conditions: NR N with prior TBI, N: G1: NR G2: 0 Age, yrs ± SD: G1: 35.3 ± 13.1 G2: 34.1 ± 10.4 Age ≥16, N (%): 92 (100) Global injury severity: NR Severity of TBI, GCS mean ± SD (range): 10.0 ± 4.0 (3 to 15) GCS score, %: 13 to 15: 36.4 9 to 12: 31.8 3 to 8: 31.8 | Depression: HADS cut-offs: 0 to 7: Normal >7: Clinically significant Other co-morbidities: PTSD: NR Other anxiety disorder: HADS (see above) Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: Fatigue Severity Scale (FSS) Visual Analog Scale for Fatigue (VAS-F), Vigor and Fatigue subscales | Depression, HADS >7, %: G1: 39.1 G2: 6.5 P<.001 Taking depression medications (%): NR Other co-morbidities: PTSD: NR Other anxiety disorder: HADS >7, %: G1: 45.7 G2: 34.8 P=.29 Irritability: NR Aggression: NR Suicidality: NR Substance use: NR Other psychiatric diagnoses: NR Health related QoL or functional status: FSS mean ± SD: G1: 4.3 ± 1.6 G2: 3.4 ± 1.1 P≤.01 VAS-F Vigor mean ± SD: G1: 5.5 ± 2.1 G2: 5.9 ± 1.7 VAS-F Fatigue mean ± SD: G1: 3.2 ± 2.4 G2: 2.7 ± 2.0

* Study does not account for difference between group size and total N included

* GCS scores recorded

Evidence Table 2 Prevalence of depression by time of assessment in studies with poorly defined TBI

Author, Year Country Setting | N with TBI^*^ (% with Depression Measure) | GCS Score | Assessment Method (mean score) | Prevalence %
Unspecified timing from injury
Aloia et al.1 1995 U.S. Neuropsychology lab | 748 (100) | NR | MMPI (66.5) | 37.0
Kinsella et al.2 1988 Australia Rehabilitation center | 39 (100) | NR | Leeds Scale (NR) | 33.0
Schofield et al.3 2006 Australia Prison | 164 (96.3) | NR | RDS (NR) | 25.0
< 3 months since injury
Rowland et al.4 2005 U.S. Rehabilitation centers | 51 (100) | NR | BDI-II (8.85) | 25.5
6 to 12 months since injury
Sebit et al.5 1998 Kenya Tertiary care center | 37 (100) | NR | SCID | 54.1
Slaughter et al.6 2003 U.S. Prison | 25 (100) | NR | PRIME: Major Remission Minor Depression | 52.0 4.0 8.0
Wade et al.7 1998 U.K. Rehabilitation center | 307 (71.0) | NR | HADS (NR) | 28.4
>12 months since injury
Brooks et al.8 1987 U.K. Rehabilitation center | 134 (100) | NR | Interview | 49.0
Holsinger et al.9 2002 U.S. Veterans database | 520 (100) | NR | Telephone SCID | 11.2
Koponen et al.10–13 2004 Finland Tertiary care center | 60 (100) | NR | SCID | 26.7
Kreutzer et al.14 2001 U.S. Trauma center | 722 (100) | NR | SCID | 42.0
Mobayed et al.15 1990 Ireland Tertiary care center | 70 (78.6) | NR | SCID | 20.0
Sliwinski et al.16–19 1998 U.S. Community sample | 100 (100) | NR | SCID | 23.0
Varney et al.20 1987 U.S. Tertiary care centers | 120 (100) | NR | SCID | 76.7
Curran et al.21–23 2000 Australia Rehabilitation center | 88 (100) | NR | BDI (14.35) | 55.7^*^
Felde et al.24 2006 U.S. Psychiatric/specialty | 218 (100) | NR | HAM-D (18.3) BDI (19.9) | 15.6
Gass et al.25 1991 U.S. Neuropsychology lab | 58 (100) | NR | MMPI (59.1) | 22.4
Hoofien et al.26 2001 Israel Rehabilitation center | 76 (100) | NR | SCL-90 (1.07) | 45.3
Kreuter et al.27–28 1998 Sweden Tertiary care center | 92 (100) | NR | HADS (5.4) | 9.8
Linn et al.29 1994 U.S. Support group | 60 (100) | NR | SCL-90-R (63.9) | 70.0
MacNiven and Finlayson30 1993 Canada Neuropsychology lab | 59 (100) Year 1 59 (23.7) Year 2 | NR | MMPI (66.24) MMPI (65.66) | 40.7 42.9
Powell et al.31 2002 U.K. Tertiary care center | 110 (85.5) | NR | HADS (8.1) | 35.0
Vasterling et al.32 2000 U.S. Tertiary care center | 87 (100) | NR | SCID | 66.7

* calculated by reviewer

Evidence Table 3 Quality rating of individual nontreatment studies

Citation | Overall Quality Score | Definition of TBI | Severity of TBI | Depression Definition | Participant Selection Criteria | Sampling Method Composite Score | LTFU | Prior Hx of Psychological Conditions
Al-Adawi et al.33 2007 | Fair | ++ | + | + | + | + | N/A | +
Aloia et al.1 1995 | Poor | − | + | + | − | + | N/A | −
Ashman et al.34 2004 | Fair | ++ | + | ++ | + | + | − | +
Bay & Donders35 2008 | Fair | + | + | + | + | + | N/A | +
Bay et al.36 2007 | Poor | ++ | + | + | − | − | N/A | +
Bay et al.37 2002 | Fair | ++ | + | + | + | + | N/A | +
Bombardier et al.38 2006 | Fair | ++ | + | + | + | ++ | ++ | +
Bowen et al.39 1998 | Good | ++ | + | + | + | +++ | ++ | +
Brooks et al.8 1987 | Poor | − | − | + | + | + | N/A | −
Brown et al.40 2004 | Fair | ++ | + | ++ | + | + | N/A | −
Bryant et al.41 2001 | Poor | − | + | ++ | + | +++ | − | −
Chamelian et al.42 2004 | Fair | ++ | + | ++ | + | + | N/A | +
Chamelian & Feinstein43 2006 | Fair | ++ | + | ++ | − | ++ | ++ | +
Chiu et al.44 2006 | Poor | ++ | + | ++ | − | +++ | ++ | −
Curran et al.21 2000 | Fair | + | + | ++ | − | + | ++ | −
Deb & Burns45 2007 | Fair | ++ | + | ++ | + | +++ | N/A | −
Deb et al.46–47 1999 | Fair | ++ | + | + | + | +++ | N/A | −
Dunlop et al.48 1991 | Fair | − | − | + | + | ++ | N/A | +
Evans et al.49 2005 | Fair | ++ | + | + | + | ++ | N/A | −
Fann et al.50 2005 | Fair | ++ | + | ++ | + | + | − | +
Fann et al.51 1995 | Fair | ++ | + | ++ | − | ++ | N/A | +
Jorge et al.52–53 1993 Fedoroff et al. 54 | Fair | ++ | + | ++ | + | + | + | +
Felde et al.24 2006 | Poor | − | − | + | + | +++ | N/A | +
Franulic et al.55 2004 | Poor | − | + | ++ | − | + | N/A | −
Frenisy et al.56 2006 | Poor | − | + | ++ | + | +++ | ++ | −
Gagnon et al.57 2006 | Fair | − | + | ++ | + | +++ | + | +
Gass & Russell25 1991 | Fair | − | + | + | + | + | N/A | +
Ghaffar et al.58 2006 | Poor | ++ | + | + | + | + | ++ | +
Gomez-Hernandez et al.59 1997 | Fair | − | + | + | + | + | + | +
Gordon et al.18 1998 | Fair | − | + | ++ | + | +++ | N/A | −
Gordon et al.19 1998 | Poor | − | + | ++ | + | +++ | N/A | −
Hawley & Joseph60 2008 | Fair | ++ | + | + | + | +++ | ++ | −
Hibbard et al.17 1998 | Fair | − | + | ++ | + | +++ | N/A | −
Hibbard et al.61 2004 | Fair | ++ | + | ++ | + | + | ++ | +
Hoge et al.62 2008 | Fair | + | + | + | + | +++ | ++ | −
Holsinger et al.9 2002 | Fair | + | + | ++ | + | +++ | N/A | −
Hoofien et al.26 2001 | Fair | − | + | ++ | + | +++ | ++ | +
Huang et al.63 2005 | Fair | ++ | + | ++ | + | +++ | ++ | +
Jorge et al.64 2004 | Fair | + | + | ++ | + | + | ++ | +
Jorge et al.65 1993 | Fair | ++ | + | ++ | + | + | + | +
Jorge et al.66 1994 | Fair | ++ | + | ++ | + | ++ | + | +
Jorge et al.67 1994 | Fair | ++ | + | ++ | + | + | + | +
Kant et al.68 1998 | Fair | ++ | + | + | − | + | N/A | +
Kashluba et al.69 2006 | Fair | ++ | + | + | + | + | ++ | +
Keiski et al.70 2007 | Poor | ++ | + | + | + | + | ++ | −
Kennedy et al.71 2005 | Poor | ++ | + | ++ | − | + | N/A | −
Kersel et al.72 2001 | Good | ++ | + | + | + | +++ | + | +
Kinsella et al.2 1988 | Fair | + | + | − | + | + | N/A | −
Koponen et al.13 2006 | Good | + | + | ++ | + | +++ | N/A | +
Koponen et al.12 2005 | Good | + | + | + | + | +++ | N/A | +
Koponen et al.10–11 2002, 2004 | Good | + | + | ++ | + | +++ | N/A | +
Kreutzer et al.14 2001 | Poor | − | + | ++ | − | + | N/A | −
Kreuter et al.27 1998 | Fair | − | + | ++ | + | +++ | N/A | −
Kreuter et al.28 1998 | Poor | − | − | ++ | + | +++ | ++ | −
Levin et al.73 2005 | Fair | ++ | + | ++ | + | + | + | +
Levin et al.74 2001 | Fair | ++ | + | ++ | + | + | N/A | +
Lima et al.75 2008 | Fair | ++ | + | + | + | +++ | N/A | −
Linn et al.29 1994 | Poor | − | + | ++ | − | + | N/A | −
MacNiven & Finlayson30 1993 | Poor | − | − | + | − | + | − | −
Marsh & Kersel76 2006 | Poor | − | + | − | + | +++ | + | −
McCauley et al.77 2005 | Fair | ++ | + | ++ | + | ++ | N/A | +
McCauley et al.78 2001 | Fair | ++ | + | + | + | + | ++ | +
McCauley et al.79 2001 | Fair | ++ | + | + | + | +++ | ++ | −
McCleary et al.80 1998 | Fair | − | + | + | + | + | + | −
Mobayed & Dinan15 1990 | Fair | ++ | + | ++ | + | ++ | N/A | −
Mooney et al.81 2005 | Fair | ++ | + | ++ | − | + | N/A | +
Mooney & Speed82 2001 | Fair | ++ | + | ++ | − | + | N/A | +
Parcell et al.22 2006 | Fair | − | + | ++ | + | +++ | ++ | +
Perlesz et al.23 2000 | Fair | − | + | ++ | + | +++ | ++ | −
Popovic et al.83 2004 | Fair | ++ | + | ++ | + | + | ++ | −
Powell et al.31 2002 | Fair | + | + | + | + | +++ | ++ | −
Rao et al.84 2008 | Fair | ++ | + | ++ | + | + | N/A | +
Rapoport et al.85 2008 | Fair | ++ | + | ++ | + | + | ++ | +
Rapoport et al.86 2003 | Good | ++ | + | ++ | + | +++ | N/A | +
Rapoport et al.87 2006 | Good | ++ | + | ++ | + | +++ | ++ | +
Rapoport et al.88 2006 | Good | ++ | + | ++ | + | +++ | + | +
Rapoport et al.89 2002 | Good | ++ | + | + | + | +++ | N/A | −
Rapoport et al.90 2003 | Fair | ++ | + | ++ | + | +++ | N/A | −
Rapoport et al.91 2005 | Fair | ++ | + | ++ | + | + | N/A | +
Rowland et al.4 2005 | Fair | + | + | ++ | + | + | N/A | +
Ruocco et al.92 2007 | Poor | ++ | + | + | + | + | ++ | −
Satz et al.93 1998 | Fair | ++ | + | + | + | +++ | N/A | −
Satz et al.94 1998 | Fair | ++ | + | + | + | +++ | N/A | −
Schofield et al.3 2006 | Poor | − | + | ++ | − | + | ++ | +
Sebit et al.5 1998 | Fair | ++ | + | ++ | + | + | ++ | +
Seel & Kreutzer95 2003 | Poor | − | + | ++ | − | + | N/A | −
Seel et al.96 2003 | Fair | + | + | ++ | + | + | ++ | −
Sherer et al.97 2007 | Fair | − | + | + | + | + | + | −
Sherman et al.98 2000 | Fair | ++ | + | + | + | ++ | N/A | −
Slaughter et al.6 2003 | Poor | − | + | + | + | +++ | N/A | −
Sliwinski et al.16 1998 | Poor | − | − | ++ | + | +++ | N/A | −
Stalnacke99 2007 | Good | ++ | + | + | + | +++ | ++ | +
Tateno et al.100 2003 | Fair | ++ | + | ++ | + | + | ++ | −
Varney et al.20 1987 | Poor | − | − | ++ | + | + | N/A | −
Vasterling et al.32 2000 | Poor | − | − | ++ | + | +++ | N/A | +
Wade et al.7 1998 | Fair | + | + | + | + | +++ | N/A | −
Whelan-Goodinson et al.101 2008 | Good | ++ | + | ++ | + | +++ | N/A | +

Evidence Table 4 Quality rating of individual treatment studies

Citation | Overall Quality Score | Randomization | Method and Blinding | Pt Selection Criteria | LTFU | Dropout Rates | Power Calculation | Statistical Issues | TBI Severity | Time Since Injury
Rapoport et al.^85^2008 | Fair | − | − | + | ++ | − | − | + | + | NR
Ashman et al.102 2009 | Good | + | + | + | + | + | + | + | + | +

Evidence Table 5 Operational definitions of TBI

Association/Tool | Operational Definition
American Congress of Rehabilitation Medicine (ACRM) | A patient with mild traumatic brain injury (mTBI) is a person who has had a traumatically induced physiological disruption of brain function, as manifested by at least one of the following: 1. any period of loss of consciousness; 2. any loss of memory for events immediately before or after the accident; 3. any alteration in mental state at the time of the accident (e.g., feeling dazed, disoriented, or confused); and 4. focal neurological deficit(s) that may or may not be transient; but where the severity of the injury does not exceed the following:; - Loss of consciousness of approximately 30 minutes or less; - After 30 minutes, an initial GCS score of 13–15; - Post-traumatic amnesia (PTA) not greater than 24 hours103
Centers for Disease Control and Prevention (CDC) | Mild TBI: A case of mTBI is an occurrence of injury to the head resulting from blunt trauma or acceleration or deceleration forces with one or more of the following conditions attributable to the head injury during the surveillance period:; - Any period of observed or self-reported transient confusion, disorientation, or impaired consciousness; - Any period of observed or self-reported dysfunction of memory (amnesia) around the time of injury;; - Observed signs of other neurological or neuropsychological dysfunction, such as:; - Seizures acutely following head injury;; - Among infants and very young children: irritability, lethargy, or vomiting following head injury;; - Symptoms among older children and adults such as headache, dizziness, irritability, fatigue, or poor concentration, when identified soon after injury, can be used to support the diagnosis of mild TBI, but cannot be used to make the diagnosis in the absence of loss of consciousness or altered consciousness. Further research may provide additional guidance in this area.; - Any period of observed or self-reported loss of consciousness lasting 30 minutes or less.; More severe brain injuries can include one or more of the following conditions attributable to the injury: loss of consciousness lasting longer than 30 minutes; PTA lasting longer than 24 hours; penetrating craniocerebral injury.104
Glasgow Coma Scale (GCS) | A clinical scale developed for assessing the depth and duration of impaired consciousness and coma that can be employed following a TBI event. Three aspects of behavior are independently measured: motor responsiveness, verbal performance, and eye opening. A cumulative score can be calculated to determine the overall severity of the head injury.105 Conventional cutoffs are: 3–8: severe TBI 9–12: moderate TBI 13–15: mild TBI
World Health Organization (WHO) | Two common criteria used to define severity of brain injury include: (i) length of time the patient is unconscious after the injury, often termed loss of consciousness and (ii) length of PTA, that is, the time period from when the patient regains consciousness until he or she regains the capacity for continuous memory. The most common way of assessing the patient’s level of consciousness is the GCS. Mild brain injury is defined as a GCS score of 13–15. PTA is often assessed more informally, by asking the patient, the family or the attending medical personnel to estimate the PTA time period. The cutoff for PTA for mild brain injury is usually 24 hours. When the length of time the patient is unconscious is used as a criterion for severity, a mild brain injury is usually defined as less than 30 minutes of unconsciousness. If a patient has a skull fracture, focal neurological deficits or hemiparesis, the brain injury is not usually considered to be mild.106
Other | Ad hoc definitions of TBI events and severity commonly include:; - Duration of loss of consciousness; - Duration of post-traumatic amnesia; - Altered mental status; - CT or MRI scans

Evidence Table 6 Depression and quality of life assessment tools

Tool/Scale | Description | Scoring/Diagnosis
Beck Depression Inventory (BDI/BDI-II) | A 21-item self-report of depression that assesses symptoms over a 7-day period. There is a 4-point scale for each item ranging from 0–3 (with 3 indicating maximum distress). The total self-rated scores range from 0 to 63.^99^ | Conventional cutoffs:99 Asymptomatic: 0–9 Mild-to-moderate: 10–18 Moderate-to-severe: 9–29 Extremely severe: 30–63 Individual studies may variously interpret the severity cutoffs assigned to specific scores.
Centers for Epidemiologic Studies-Depression (CES-D) | The 20-item CES-D asks respondents to rate the number of days (0–7) during the past week they experienced depressed symptoms. Higher scores denote greater levels of depression. As a measure of depressive symptoms, it contains Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM- IV_ related items of depressed mood, sleep disturbance, weight change, diminished concentration, worthlessness, anhedonia, and decreased energy.36 | Conventional cutoffs:36 Mild: 16–20 Moderate: 21–26 Severe: 27–60 Individual studies may variously interpret the severity cutoffs assigned to specific scores.
WHO Composite International Diagnostic Interview (CIDI) | A comprehensive, fully standardized diagnostic interview for the assessment of mental disorders according to the definitions and criteria of the International Classification of Diseases version 10 (ICD-10) Diagnostic Criteria for Research and the DSM-III, Revised.107 | The instrument contains 276 symptom questions, many of which are coupled with probe questions to evaluate symptom severity Diagnoses based on ICD-10 criteria and derived from patient responses to the symptom and probe questions.107
Clinical Interview Schedule-Revised (CIS-R) | Often reported in British studies, this structured interview instrument is useful for large surveys that use trained (but not necessarily expert) interviewers, or it can be completed as a self-report in a computerized version. Depression is one of 14 areas of symptoms that are elicited. It can provide both ICD-10 diagnoses and also, separately, severity scores. It takes less time to administer than the CIDI.108 | Can be used to generate a total score, as well as diagnostic categories according to ICD-10 criteria (similar to the CIDI).108
National Institute of Mental Health Diagnostic Interview Schedule (DIS-III-A) | A highly structured interview designed to make diagnoses by the following three systems: (1) DSM-III, published in 1980, (2) the Feighner criteria, published in 1972, and (3) the Research Diagnostic Criteria, published in 1978. Diagnostic questions incorporate elements from the three included systems. This highly structured interview allows for lay interviewers to perform the many tasks involved in making an accurate diagnosis.109 | All diagnoses are made on a lifetime basis first, and then the interview inquires as to how recently the last symptom was experienced. On the basis of these answers it decides whether the disorder is current, defined for four time periods: the last 2 weeks, the last month, the last 6 months, and the last year. It also ascertains the age at the last symptom; the age at which the first symptom appeared; and, in the upcoming version 3, it will ascertain whether medical care was ever sought for symptoms of that disorder. In addition to diagnostic results, the DIS also provides a total symptom count across diagnoses for each of the three systems and a count of the number of criteria met for each diagnosis, whether or not that diagnosis is positive.109
Diagnostic and Statistical Manual of Mental Disorders (DSM-IV-TR, DSM-IV, DSM-III-R) | Standard manual for diagnosis published by the American Psychiatric Association and accepted nationally and increasingly worldwide. Provides diagnostic criteria with operationalized categorical thresholds.110 | Depression is diagnosed as an episode, and then as a major depressive disorder (MDD) if depression is present without manic episodes. Specifiers allow depiction of severity, psychotic features, degrees of remission, chronicity, catatonic features, melancholic features, atypical features, and postpartum onsets. The diagnostician needs considerable training for use, and may also note Longitudinal Course Specifiers (With and Without Interepisode Recovery) or Seasonal Pattern.110
European Brain Injury Questionnaire (EBIQ) | 63 questions regarding diverse “problems or difficulties that people sometimes experience in their lives” and it is requested that answers should concern the preceding month. The final question concerns “problems in general.”111 | The response alternatives are “not at all,” “a little” or “a lot,” are subsequently coded numerically as 1, 2, and 3 respectively.111
Functional Independence/Assessment Measures (FIM+FAM) | The Functional Assessment Measure (FAM) was developed for use in brain-injured individuals. FAM consists of 12 items intended to be added to the 18 items of the Functional Independence Measure (FIM). The FAM items emphasize the cognitive and psychosocial aspects of the disability. They total 30 items, each assessed on seven levels which, when summed, may be used to estimate a person’s need for assistance (burden of care). The lower the score, the more severe the indicated dysfunction. The 18 FIM items concerning self-care, bladder and bowel control, mobility, and locomotion are indicators of motor disability. The 12 FAM items covering comprehension, expression, social interaction, emotional state, adaptation to limitations, ability to work, problem solving, memory, powers of concentration, and ability to form an opinion on safety are indicators of communication and psychosocial and cognitive functioning.27 | An interviewer administered questionnaire. A score of 7 represents complete independence for a given item and a score of 1 represents complete dependence.60
General Health Questionnaire (GHQ) | A self-administered screening questionnaire designed for use in consulting settings aimed at directing those with a diagnosable psychiatric disorder. It concerns itself with two major classes of phenomena: inability to carry out one’s normal “healthy” functions, and the appearance of new phenomena of a distressing nature.112 | The GHQ may be thought of as comprising a set of questions that form a “lowest common multiple” of symptoms which will be encountered in the various differentiated syndromes of mental disorder, consisting of symptoms which best differentiate psychiatric patients from those who consider themselves to be well. The full-length version requires any 12 symptoms from a set of 60 total in order to identify probable cases. Scaled versions of the GHQ exist.112
Hospitality Anxiety and Depression Scale (HADS) | A self-assessment questionnaire with subscales for anxiety and depression. Each subscale contains 7 items, with four possible answers for each, graded 0–3.^75^ | Conventional cutoffs, individual subscales: Normal: 0–7 Borderline: 8–14 Abnormal: 15–21 The total score is obtained by adding two subscales and considering normal (0–14), borderline (15–28), and abnormal (29–42).75 Individual studies may variously interpret the severity cutoffs assigned to specific scores.
Hamilton Depression Rating Scale (HAM-D) | This 17-item scale has often been used in expanded versions with 21 or 25 items. Consistently accepted since publication in 1960 as a standard severity measure for antidepressant medication outcome trials, its value derives from relatively balanced coverage of both somatic (sleep, appetite, energy) and psychological (sadness, guilt, suicidal thinking, insight) symptoms that are characteristic of depression.113 | About half of the items are scored from 0 to 4; the others are measured from 0 to 2. Scores of 8 to 17 indicate subthreshold depression or dysthymic mood, 18 to 21 reflects a mild form of depression that will generally reach threshold for diagnosis, 22 to 24 is considered moderate, and 25 or more is often considered severe.113
Head Injury Behavior Rating Scale (HIBS) | A questionnaire containing 20 items describing behavioral problems often associated with traumatic brain injury (TBI). The patient is asked to indicate whether the identified behavior has become a problem for them since their TBI, and if so, how much distress this causes for them. The relatives’ version of this measure contains the same 20 items as those in the TBI patients’ version. The primary difference is that the caregiver is asked to rate the presence/absence of the problem behaviors in the TBI patient, and then rate how much distress it causes for them.76 | In both the patient and caregiver versions, behavioral problems assessed as either yes/no, while distress is rated on a 4-point scale from 1 (no distress) to 4 (severe distress).114
Leeds Scales for Anxiety and Depression | 15-item self assessment that describes common symptoms of anxiety and depression. The scales can be separated or administered together, and are derived from the HAM-D and the Hamilton Anxiety Scale.115 | Conventional cutoffs: A score of 6–7 for both the depression and anxiety scores provides the most satisfactory division between healthy and sick populations.115
Millon Clinical Multiaxial Inventory-III (MCMI-III) | The MCMI-III is a 175-item self-report true-false inventory. It was designed to measure the DSM-IV personality disorders in addition to depressive, sadistic/aggressive and masochistic/self- defeating personality disorders. The instrument distinguishes the severe personality disorders of schizotypal, borderline, and paranoid from the other personality patterns. It contains scales measuring clinical symptoms and conditions, including anxiety, somatoform disorder, mania, dysthymia, alcohol and drug dependence, post-traumatic stess disorder, thought disorder, major depression, and delusional disorder.92 | The instrument uses base rate (BR) scores, which attempt to anchor scales to the base rate of psychiatric conditions in the population. The inventory also possesses four measures of response style. The validity index is sensitive to a random response set. The disclosure, desirability, and debasement scales, called the modifier indices, are measures of response style and dissimulation. The disclosure index is a measure of the overall number of symptoms reported on the inventory; elevations on this scale indicate a possible fake-bad response set, while very low scores may be indicative of a fake-good or defensive response set. The debasement index provides an indication of exaggerated psychopathology, while the desirability index gauges the tendency to present oneself in an overly positive light.92
Minnesota Multiphasic Personality Inventory (MMPI, MMPI-2) | Both the MMPI and MMPI-2 are subdivided into the same 10 clinical scales designed to assess an individual’s perceived emotional, social, and behavioral functioning, as well as three validity scales, designated L, F, and K, designed to detect deviant test-taking attitudes.116 | Scales:; 1. Hypochondriasis; 2. Depression; 3. Hysteria; 4. Psychotic deviate; 5. Masculinity-femininity; 6. Paranoia; 7. Psychasthenia; 8. Schizophrenia; 9. Hypomania; 10. Social introversion; Mean subscale scores can be compared with a normative population to determine elevations.25
Neurobehavioral Functioning Index- Depression (NFI-D) | The NFI is a factor-analytically derived and validated assessment tool. It consists of 6 scales—depression, somatic, memory/attention, communication, aggression, and motor—dealing with category-specific problems and symptoms characteristically experienced by people with recent onset of neurological and behavioral impairment. Seventy items are rated on a 5-point Likert-type scale and measure the frequency of behaviors and symptoms demonstrated by the identified participant (1 = never; 2 = rarely; 3 = sometimes; 4 = often; 5 = always). Higher scores indicate greater neurobehavioral problems.117 | < 28: Not likely to be depressed 29–42: Borderline > 43: Highly correlated with clinical depression117
Neurobehavioral Rating Scale (NRS) | It contains 29 items subdivided into five factor categories and one nonfactor category. Factor I is memory difficulties, self-appraisal difficulties, reduction in affection, difficulties in flexible thinking, conceptual disorganization, disorientation, planning capacity problems, decline in initiative, and motivation. Factor II is anxiety, depressive moods, withdrawal. Factor III is hyperactivity—agitation, unusual thought content, mood swings, irritability, disinhibition, excitation, hostility, and suspiciousness. Factor IV is attention difficulties, loss of vigilance, motor slowing, and susceptibility to mental fatigue. Factor V is articulatory disorders, difficulties in oral expression, and difficulties in oral comprehension.56 | Based on a 4-point scale (absent, mild, moderate, and severe). The ratings for each item are defined on the basis of the potential impact of the behavior on social and occupational independence.79
Personality Assessment Inventory (PAI) | Self-administered, objective inventory of adult personality. 344 items comprising 22 nonoverlapping full scales: 4 validity scales, 11 clinical scales, 5 treatment consideration scales, and 2 interpersonal scales. 27 critical items that act as indicators of potential crisis situations and have very low endorsement in normal sample. Responses to critical items facilitate followup questioning.118 | Depression diagnosed if PAI score >70.^70^ Individual studies may variously interpret the severity cutoffs assigned to specific scores.
Patient Health Questionnaire-9 (PHQ-9) | The PHQ-9 parallels the 9 diagnostic symptom criteria that define DSM-IV MDD. The format and temporal framework of the items also correspond to the DSM-IV criteria and will facilitate the follow-up review of symptoms and diagnostic process. Unlike most other measures of depression, the PHQ-9 was developed, tested, and refined for use with medical patients.50 | The PHQ-9 is a self-report measure that asks if the subject had been bothered by the following problems in the past 2 weeks: (a) little pleasure or interest in doing things, (b) feeling down, depressed, or hopeless, (c) sleeping too little or too much, (d) feeling tired or having little energy, (e) poor appetite or overeating, (f ) feelings of worthlessness or guilt, (g) concentration problems, (h) psychomotor retardation or agitation, and (i) thoughts of suicide. Subjects are asked to rate how often each symptom occurred: 0 (not at all), 1 (several days), 2 (more than half the days), or 3 (nearly every day). Several methods of depression screening using the PHQ-9. It can be scored on the basis of at least 5 symptom endorsed “more than half the days” (suicidal ideation could be “several days”), with at least one being a “cardinal symptom,” that is, either (a) anhedonia or (b) depressed mood.38,50 Suggested cutoffs:50 Mild: 5–9 Moderate: 10–14 Moderately severe: 15–19 Severe: ≥20 depression Individual studies may variously interpret the severity cutoffs assigned to specific scores.
Profile of Mood States (POMS) | A standardized list of 65 adjectives (happy, sad, angry, etc.) rated by the subject to measures six affective states, including a 15-item depressed mood. It uses a 0–5 Likert-type scale (0 = not at all; 5 = extremely).36 | Range 0–60; higher scores indicate more severe depression.36
Primary Care Evaluation of Mental Disorders (PRIME- MD) | A standardized, clinician-administered instrument that was developed to assess psychiatric disorders in primary care settings. It has been shown to be a psychometrically useful tool in identifying mental disorders in the medical setting as well as in research. (#461 Slaughter) Two components: a one-page patient questionnaire (PQ) that is completed by the patient before seeing the physician, and a 12-page clinician evaluation guide (CEG), a structured interview form that the physician uses to follow up on positive responses on the PQ.119 | PQ: 26 yes/no questions about symptoms and signs present during the past month, divided into five diagnostic areas (mood, anxiety, somatoform, alcohol, and eating disorders). Patient responses to the PQ indicate to the physician which, if any, of the five diagnostic modules in the CEG should be used. CEG: Using the CEG, the clinician determines the presence or absence of 18 possible current mental disorders in the five broad diagnostic categories by asking specific questions based on the diagnostic criteria (often simplified for primary care use) contained in DSM-III-R.119
Referral Decision Scale (RDS) | Intended to provide researchers and trained correctional staff with a quick, easily administered/scored tool for screening jail detainees for serious mental illnesses (i.e., schizophrenia and the major affective disorders). Although offered as three subscales for identifying individuals with schizophrenia, bipolar, or depressive disorders, the RDS has not yet been demonstrated capable of distinguishing among these three major diagnostic categories.120 | 14 yes/no questions divided into three subscales and administered by trained individuals.120
Rivermead Post- Concussion Disorder Questionnaire (RPCQ) | It contains 18 questions probing symptoms of: headache, dizziness, nausea, noise sensitivity, sleep disturbance, fatigue, irritability, depression, frustration, forgetfulness, poor concentration, taking longer to think, blurred vision, light sensitivity, double vision, and restlessness.58 | Self-report checklist in which patients rate Post-Concussion Syndrome symptoms according to whether they are no more of a problem, a mild problem, a moderate problem, or a severe problem in comparison with how they were functioning prior to their injury.121
Schedule for Clinical Assessment in Neuropsychiatry (SCAN) | Developed with the aim of providing a comprehensive procedure for clinical examination that is also capable of generating many of the categories of the ICD-10 and DSM-III.122 | It includes the Present State Examination 10th edition, the Item Group Checklist (IGCLIST), in which 59 item groups, each defined in terms of PSE-10 items, are rated directly; and the Clinical Information Schedule (CLINFO), containing summary items on intellectual level, personality disorders, social disablement, and clinical diagnosis. Information is obtained from the same sources as IGCLIST (case records, clinicians, and other informants).122
Structured Clinical Interview for the DSM-IV (SCID) | A structured interview assessment approach that operationalizes scoring elements of DSM criteria. It has been developed through the work of clinicians and researchers alike over the past 5 decades and is currently in its fourth revision (DSM-IV-TR).71 | MDD: Five (or more) of the following symptoms have been present during the same 2-week period and represent a change from previous functioning; at least one of the symptoms is either item 1 or item 2:; 1. Depressed mood most of the day, nearly every day; 2. Markedly diminished interest or pleasure in all, or almost all, activities most of the day, nearly every day; 3. Significant weight loss when not dieting or weight gain (e.g., a change of more than 5% of body weight in a month), or decrease or increase in appetite nearly every day; 4. Insomnia or hypersomnia nearly every day; 5. Psychomotor agitation or retardation nearly every day; 6. Fatigue or loss of energy nearly every day; 7. Feelings of worthlessness or excessive or inappropriate guilt (which may be delusional) nearly every day (not merely self-reproach or guilt about being sick); 8. Diminished ability to think or concentrate, or indecisiveness, nearly every day (as indicated by either subjective account or observation made by others); 9. Recurrent thoughts of death (not just fear of dying), recurrent suicidal ideation without a specific plan, or a suicide attempt or a specific plan for committing suicide.71
Symptom Checklist (SCL-90-R, SCL-90, SCL-20) | A psychiatric checklist that produces psychopathology scores and a Global Severity Index (GSI), which reflects the clinical severity of all symptoms. The scale allows for the comparison of participants’ scores to a U.S. normative sample.26 | Can be administered as the full-length, 90-item version or a scaled version. The full-length version produces nine psychopathology scales. Results are compared with percentiles of the normative sample to determine elevations.26
Short Form Health Survey (SF-36, SF-12) | Self-report questionnaire designed to measure health and quality of life from the respondent’s point of view. Available in full-length or scaled versions.19 | 1 (excellent) to 5 (poor) scoring on eight scales (full length): physical functioning (extent to which health limits physical activities), role functioning-physical (extent to which physical health interferes with work or other daily activities), bodily pain (intensity of pain and its effect on normal work), general health (personal evaluation of health), vitality (feeling energetic versus feeling tired), social functioning (extent to which physical health or emotional problems interfere with normal social activities), role functioning-emotional (extent to which emotional problems interfere with work or other daily activities), and mental health (general mental health, including depression, anxiety, behavioral-emotional control, and general positive affect).19
Visual Analog Scale for Depression (VAS-D) | Visual method for assessing depression. The distance in millimeters from the nondepressed side is the dependent measure.78 Scoring is not usually applied to severity measures, but items can be compared within subjects for change in scoring with repeated measures. | Depressed mood is measured by asking the patient to make a mark on a 100 mm line between the statements “‘I am not depressed”‘ to “‘I have never been more depressed.”78
Short form of the WHO Quality of Life questionnaire (WHOQOL-BREF) | 26 items or “facets” assessed. Facet defined as a behavior (e.g., walking), a state of being (e.g., vitality), a capacity or potential (e.g., the ability to move around), or a subjective perception or experience (e.g., feeling pain). 26 items include 2 items from the overall quality of life and general health facet and 24 facets further categorized into four domains: physical capacity (7 items), psychological well-being (6 items), social relationships (3 items), and environment (8 items).44 | Each item uses a scale from 1 to 5, with a higher score indicating a higher quality of life. Domain scores are calculated by multiplying the mean of all facet scores included in each domain by a factor of 4, and potential scores for each domain vary from 4 to 20.^44^
Zung Depression Scale (ZDS) | A 20 item self-reported questionnaire descriptive of somatic and affective characteristics of depression.63 | Each item rated from 1 to 4 to determine severity. Different cutoffs have been used for measuring depression: 55;≥39.^63,83^

## References

1 Aloia MS, Long CJ, Allen JB. Depression among the head-injured and non-head-injured: a discriminant analysis. Brain Inj. 08–09. 1995;9(6):575-583. [pmid: 7581353].
2 Kinsella G, Moran C, Ford B, et al. Emotional disorder and its assessment within the severe head injured population. Psychol Med. 02. 1988;18(1):57-63. [pmid: 2966415].
3 Schofield PW, Butler TG, Hollis SJ, et al. Neuropsychiatric correlates of traumatic brain injury (TBI) among Australian prison entrants. Brain Inj. 12. 2006;20(13–14):1409-1418. [pmid: 17378233].
4 Rowland SM, Lam CS, Leahy B. Use of the Beck Depression Inventory-II (BDI-II) with persons with traumatic brain injury: analysis of factorial structure. Brain Inj. 02. 2005;19(2):77-83. [pmid: 15841751].
5 Sebit MB, Siziya S, Ndetei DM, et al. Study of psychiatric consequences of closed head injury at the Kenyatta National Hospital. East Afr Med J. 06. 1998;75(6):332-335. [pmid: 9803614].
6 Slaughter B, Fann JR, Ehde D. Traumatic brain injury in a county jail population: prevalence, neuropsychological functioning and psychiatric disorders. Brain Inj. 09. 2003;17(9):731-741. [pmid: 12850940].
7 Wade DT, King NS, Wenden FJ, et al. Routine follow up after head injury: a second randomised controlled trial. J Neurol Neurosurg Psychiatry. 08. 1998;65(2):177-183. [pmid: 9703167].
8 Brooks N, Campsie L, Symington C, et al. The effects of severe head injury on patient and relative within seven years of injury. Journal of Head Trauma Rehabilitation. 1987;2(3):1-13.
9 Holsinger T, Steffens DC, Phillips C, et al. Head injury in early adulthood and the lifetime risk of depression. Arch Gen Psychiatry. 01. 2002;59(1):17-22. [pmid: 11779276].
10 Koponen S, Taiminen T, Kairisto V, et al. APOE-epsilon4 predicts dementia but not other psychiatric disorders after traumatic brain injury. Neurology. 08. 24. 2004;63(4):749-750. [pmid: 15326261].
11 Koponen S, Taiminen T, Portin R, et al. Axis I and II psychiatric disorders after traumatic brain injury: a 30-year follow-up study. Am J Psychiatry. 08. 2002;159(8):1315-1321. [pmid: 12153823].
12 Koponen S, Taiminen T, Honkalampi K, et al. Alexithymia after traumatic brain injury: its relation to magnetic resonance imaging findings and psychiatric disorders. Psychosom Med. 09–10. 2005;67(5):807-812. [pmid: 16204442].
13 Koponen S, Taiminen T, Kurki T, et al. MRI findings and Axis I and II psychiatric disorders after traumatic brain injury: a 30-year retrospective follow-up study. Psychiatry Res. 04. 30. 2006;146(3):263-270. [pmid: 16507345].
14 Kreutzer JS, Seel RT, Gourley E. The prevalence and symptom rates of depression after traumatic brain injury: a comprehensive examination. Brain Inj. 07. 2001;15(7):563-576. [pmid: 11429086].
15 Mobayed M, Dinan TG. Buspirone/prolactin response in post head injury depression. J Affect Disord. 08. 1990;19(4):237-241. [pmid: 2146299].
16 Sliwinski M, Gordon WA, Bogdany J. The Beck Depression Inventory: is it a suitable measure of depression for individuals with traumatic brain injury?. J Head Trauma Rehabil. 08. 1998;13(4):40-46. [pmid: 9651238].
17 Hibbard MR, Uysal S, Kepler K, et al. Axis I psychopathology in individuals with traumatic brain injury. J Head Trauma Rehabil. 08. 1998;13(4):24-39. [pmid: 9651237].
18 Gordon WA, Brown M, Sliwinski M, et al. The enigma of “hidden” traumatic brain injury. J Head Trauma Rehabil. 12. 1998;13(6):39-56. [pmid: 9885317].
19 Gordon WA, Sliwinski M, Echo J, et al. The benefits of exercise in individuals with traumatic brain injury: a retrospective study. J Head Trauma Rehabil. 08. 1998;13(4):58-67. [pmid: 9651240].
20 Varney NR, Martzke JS, Roberts RJ. Major depression in patients with closed head injury. Neuropsychology. 05. 1987;1(1):7-9.
21 Curran CA, Ponsford JL, Crowe S. Coping strategies and emotional outcome following traumatic brain injury: a comparison with orthopedic patients. J Head Trauma Rehabil. 12. 2000;15(6):1256-1274. [pmid: 11056407].
22 Parcell DL, Ponsford JL, Rajaratnam SM, et al. Self-reported changes to nighttime sleep after traumatic brain injury. Arch Phys Med Rehabil. 02. 2006;87(2):278-285. [pmid: 16442985].
23 Perlesz A, Kinsella G, Crowe S. Psychological distress and family satisfaction following traumatic brain injury: injured individuals and their primary, secondary, and tertiary carers. J Head Trauma Rehabil. 06. 2000;15(3):909-929. [pmid: 10785622].
24 Felde AB, Westermeyer J, Thuras P. Comorbid traumatic brain injury and substance use disorder: childhood predictors and adult correlates. Brain Inj. 01. 2006;20(1):41-49. [pmid: 16403699].
25 Gass CS, Russell EW. MMPI profiles of closed head trauma patients: impact of neurologic complaints. J Clin Psychol. 03. 1991;47(2):253-260. [pmid: 2030130].
26 Hoofien D, Gilboa A, Vakil E, et al. Traumatic brain injury (TBI) 10–20 years later: a comprehensive outcome study of psychiatric symptomatology, cognitive abilities and psychosocial functioning. Brain Inj. 03. 2001;15(3):189-209. [pmid: 11260769].
27 Kreuter M, Dahllof AG, Gudjonsson G, et al. Sexual adjustment and its predictors after traumatic brain injury. Brain Inj. 05. 1998;12(5):349-368. [pmid: 9591141].
28 Kreuter M, Sullivan M, Dahllof AG, et al. Partner relationships, functioning, mood and global quality of life in persons with spinal cord injury and traumatic brain injury. Spinal Cord. 04. 1998;36(4):252-261. [pmid: 9589525].
29 Linn RT, Allen K, Willer BS. Affective symptoms in the chronic stage of traumatic brain injury: a study of married couples. Brain Inj. 02–03. 1994;8(2):135-147. [pmid: 8193633].
30 MacNiven E, Finlayson MA. The interplay between emotional and cognitive recovery after closed head injury. Brain Inj. 05–06. 1993;7(3):241-246. [pmid: 8508180].
31 Powell J, Heslin J, Greenwood R. Community based rehabilitation after severe traumatic brain injury: a randomised controlled trial. J Neurol Neurosurg Psychiatry. 02. 2002;72(2):193-202. [pmid: 11796769].
32 Vasterling JJ, Constans JI, Hanna-Pladdy B. Head injury as a predictor of psychological outcome in combat veterans. J Trauma Stress. 07. 2000;13(3):441-451. [pmid: 10948484].
33 Al-Adawi S, Dorvlo AS, Al-Naamani A, et al. The ineffectiveness of the Hospital Anxiety and Depression Scale for diagnosis in an Omani traumatic brain injured population. Brain Inj. 04. 2007;21(4):385-393. [pmid: 17487636].
34 Ashman TA, Spielman LA, Hibbard MR, et al. Psychiatric challenges in the first 6 years after traumatic brain injury: cross-sequential analyses of Axis I disorders. Arch Phys Med Rehabil. 04. 2004;85(4 Suppl 2):S36-42. [pmid: 15083420].
35 Bay E, Donders J. Risk factors for depressive symptoms after mild-to-moderate traumatic brain injury. Brain Inj. 03. 2008;22(3):233-241. [pmid: 18297595].
36 Bay E, Hagerty BM, Williams RA. Depressive symptomatology after mild-to-moderate traumatic brain injury: a comparison of three measures. Arch Psychiatr Nurs. 02. 2007;21(1):2-11. [pmid: 17258103].
37 Bay E, Hagerty BM, Williams RA, et al. Chronic stress, sense of belonging, and depression among survivors of traumatic brain injury. J Nurs Scholarsh. 2002;34(3):221-6. [pmid: 12237983].
38 Bombardier CH, Fann JR, Temkin N, et al. Posttraumatic stress disorder symptoms during the first six months after traumatic brain injury. J Neuropsychiatry Clin Neurosci. Fall. 2006;18(4):501-508. [pmid: 17135375].
39 Bowen A, Neumann V, Conner M, et al. Mood disorders following traumatic brain injury: identifying the extent of the problem and the people at risk. Brain Inj. 03. 1998;12(3):177-190. [pmid: 9547948].
40 Brown SA, McCauley SR, Levin HS, et al. Perception of health and quality of life in minorities after mild-to-moderate traumatic brain injury. Appl Neuropsychol. 2004;11(1):54-64. [pmid: 15471747].
41 Bryant RA, Marosszeky JE, Crooks J, et al. Posttraumatic stress disorder and psychosocial functioning after severe traumatic brain injury. J Nerv Ment Dis. 02. 2001;189(2):109-113. [pmid: 11225683].
42 Chamelian L, Reis M, Feinstein A. Six-month recovery from mild to moderate Traumatic Brain Injury: the role of APOE-epsilon4 allele. Brain. 12. 2004;127(Pt 12):2621-2628. [pmid: 15496436].
43 Chamelian L, Feinstein A. The effect of major depression on subjective and objective cognitive deficits in mild to moderate traumatic brain injury. J Neuropsychiatry Clin Neurosci. Winter. 2006;18(1):33-38. [pmid: 16525068].
44 Chiu WT, Huang SJ, Hwang HF, et al. Use of the WHOQOL-BREF for evaluating persons with traumatic brain injury. J Neurotrauma. 11. 2006;23(11):1609-1620. [pmid: 17115908].
45 Deb S, Burns J. Neuropsychiatric consequences of traumatic brain injury: a comparison between two age groups. Brain Inj. 03. 2007;21(3):301-307. [pmid: 17453758].
46 Deb S, Lyons I, Koutzoukis C. Neurobehavioural symptoms one year after a head injury. Br J Psychiatry. 04. 1999;174:360-365. [pmid: 10533556].
47 Deb S, Lyons I, Koutzoukis C, et al. Rate of psychiatric illness 1 year after traumatic brain injury. Am J Psychiatry. 03. 1999;156(3):374-378. [pmid: 10080551].
48 Dunlop TW, Udvarhelyi GB, Stedem AF, et al. Comparison of patients with and without emotional/behavioral deterioration during the first year after traumatic brain injury. J Neuropsychiatry Clin Neurosci. Spr. 1991;3(2):150-156. [pmid: 1821228].
49 Evans CC, Sherer M, Nick TG, et al. Early impaired self-awareness, depression, and subjective well-being following traumatic brain injury. J Head Trauma Rehabil. 11–12. 2005;20(6):488-500. [pmid: 16304486].
50 Fann JR, Bombardier CH, Dikmen S, et al. Validity of the Patient Health Questionnaire-9 in assessing depression following traumatic brain injury. J Head Trauma Rehabil. 11–12. 2005;20(6):501-511. [pmid: 16304487].
51 Fann JR, Katon WJ, Uomoto JM, et al. Psychiatric disorders and functional disability in outpatients with traumatic brain injuries. Am J Psychiatry. 10. 1995;152(10):1493-1499. [pmid: 7573589].
52 Jorge RE, Robinson RG, Arndt S. Are there symptoms that are specific for depressed mood in patients with traumatic brain injury?. J Nerv Ment Dis. 02. 1993;181(2):91-99. [pmid: 8426177].
53 Jorge RE, Robinson RG, Arndt SV, et al. Depression following traumatic brain injury: a 1 year longitudinal study. J Affect Disord. 04. 1993;27(4):233-243. [pmid: 8509524].
54 Fedoroff JP, Starkstein SE, Forrester AW, et al. Depression in patients with acute traumatic brain injury. Am J Psychiatry. 07. 1992;149(7):918-923. [pmid: 1609872].
55 Franulic A, Carbonell CG, Pinto P, et al. Psychosocial adjustment and employment outcome 2, 5 and 10 years after TBI. Brain Inj. 02. 2004;18(2):119-129. [pmid: 14660225].
56 Frenisy MC, Benony H, Chahraoui K, et al. Brain injured patients versus multiple trauma patients: some neurobehavioral and psychopathological aspects. J Trauma. 05. 2006;60(5):1018-1026. [pmid: 16688064].
57 Gagnon J, Bouchard MA, Rainville C, et al. Inhibition and object relations in borderline personality traits after traumatic brain injury. Brain Inj. 01. 2006;20(1):67-81. [pmid: 16403702].
58 Ghaffar O, McCullagh S, Ouchterlony D, et al. Randomized treatment trial in mild traumatic brain injury. J Psychosom Res. 08. 2006;61(2):153-160. [pmid: 16880017].
59 Gomez-Hernandez R, Max JE, Kosier T, et al. Social impairment and depression after traumatic brain injury. Arch Phys Med Rehabil. 12. 1997;78(12):1321-1326. [pmid: 9421985].
60 Hawley CA, Joseph S. Predictors of positive growth after traumatic brain injury: a longitudinal study. Brain Inj. 05. 2008;22(5):427-435. [pmid: 18415723].
61 Hibbard MR, Ashman TA, Spielman LA, et al. Relationship between depression and psychosocial functioning after traumatic brain injury. Arch Phys Med Rehabil. 04. 2004;85(4 Suppl 2):S43-53. [pmid: 15083421].
62 Hoge CW, McGurk D, Thomas JL, et al. Mild traumatic brain injury in U.S. Soldiers returning from Iraq. N Engl J Med. 01. 31. 2008;358(5):453-463. [pmid: 18234750].
63 Huang DB, Spiga R, Koo H. Use of the Zung depression scale in patients with traumatic brain injury: 1 year post-injury. Brain Inj. 10. 2005;19(11):903-908. [pmid: 16299933].
64 Jorge RE, Robinson RG, Moser D, et al. Major depression following traumatic brain injury. Arch Gen Psychiatry. 01. 2004;61(1):42-50. [pmid: 14706943].
65 Jorge RE, Robinson RG, Arndt SV, et al. Comparison between acute- and delayed-onset depression following traumatic brain injury. J Neuropsychiatry Clin Neurosci. Winter. 1993;5(1):43-49. [pmid: 8428134].
66 Jorge RE, Robinson RG, Starkstein SE, et al. Influence of major depression on 1-year outcome in patients with traumatic brain injury. J Neurosurg. 11. 1994;81(5):726-733. [pmid: 7931619].
67 Jorge RE, Robinson RG, Starkstein SE, et al. Depression and anxiety following traumatic brain injury. J Neuropsychiatry Clin Neurosci. Fall. 1993;5(4):369-374. [pmid: 8286933].
68 Kant R, Duffy JD, Pivovarnik A. Prevalence of apathy following head injury. Brain Inj. 01. 1998;12(1):87-92. [pmid: 9483342].
69 Kashluba S, Casey JE, Paniak C. Evaluating the utility of ICD-10 diagnostic criteria for postconcussion syndrome following mild traumatic brain injury. J Int Neuropsychol Soc. 01. 2006;12(1):111-118. [pmid: 16433950].
70 Keiski MA, Shore DL, Hamilton JM. The role of depression in verbal memory following traumatic brain injury. Clin Neuropsychol. 09. 2007;21(5):744-761. [pmid: 17676541].
71 Kennedy RE, Livingston L, Riddick A, et al. Evaluation of the Neurobehavioral Functioning Inventory as a depression screening tool after traumatic brain injury. J Head Trauma Rehabil. 11–12. 2005;20(6):512-526. [pmid: 16304488].
72 Kersel DA, Marsh NV, Havill JH, et al. Psychosocial functioning during the year following severe traumatic brain injury. Brain Inj. 08. 2001;15(8):683-696. [pmid: 11485609].
73 Levin HS, McCauley SR, Josic CP, et al. Predicting depression following mild traumatic brain injury. Arch Gen Psychiatry. 05. 2005;62(5):523-528. [pmid: 15867105].
74 Levin HS, Brown SA, Song JX, et al. Depression and posttraumatic stress disorder at three months after mild to moderate traumatic brain injury. J Clin Exp Neuropsychol. 12. 2001;23(6):754-769. [pmid: 11910542].
75 Lima DP, Simao Filho C, Abib Sde C, et al. Quality of life and neuropsychological changes in mild head trauma. Late analysis and correlation with S100B protein and cranial CT scan performed at hospital admission. Injury. 05. 2008;39(5):604-611. [pmid: 18329647].
76 Marsh NV, Kersel DA. Frequency of behavioural problems at one year following traumatic brain injury: correspondence between patient and caregiver reports. Neuropsychol Rehabil. 12. 2006;16(6):684-694. [pmid: 17127573].
77 McCauley SR, Boake C, Pedroza C, et al. Postconcussional disorder: Are the DSM-IV criteria an improvement over the ICD-10?. J Nerv Ment Dis. 08. 2005;193(8):540-550. [pmid: 16082299].
78 McCauley SR, Boake C, Levin HS, et al. Postconcussional disorder following mild to moderate traumatic brain injury: anxiety, depression, and social support as risk factors and comorbidities. J Clin Exp Neuropsychol. 12. 2001;23(6):792-808. [pmid: 11910545].
79 McCauley SR, Levin HS, Vanier M, et al. The neurobehavioural rating scale-revised: sensitivity and validity in closed head injury assessment. J Neurol Neurosurg Psychiatry. 11. 2001;71(5):643-651. [pmid: 11606677].
80 McCleary C, Satz P, Forney D, et al. Depression after traumatic brain injury as a function of Glasgow Outcome Score. J Clin Exp Neuropsychol. 04. 1998;20(2):270-279. [pmid: 9777481].
81 Mooney G, Speed J, Sheppard S. Factors related to recovery after mild traumatic brain injury. Brain Inj. 11. 2005;19(12):975-987. [pmid: 16263640].
82 Mooney G, Speed J. The association between mild traumatic brain injury and psychiatric conditions. Brain Inj. 10. 2001;15(10):865-877. [pmid: 11595083].
83 Popovic V, Pekic S, Pavlovic D, et al. Hypopituitarism as a consequence of traumatic brain injury (TBI) and its possible relation with cognitive disabilities and mental distress. J Endocrinol Invest. 12. 2004;27(11):1048-1054. [pmid: 15754737].
84 Rao V, Spiro J, Vaishnavi S, et al. Prevalence and types of sleep disturbances acutely after traumatic brain injury. Brain Inj. 05. 2008;22(5):381-386. [pmid: 18415718].
85 Rapoport MJ, Chan F, Lanctot K, et al. An open-label study of citalopram for major depression following traumatic brain injury. J Psychopharmacol. 11. 2008;22(8):860-864. [pmid: 18208921].
86 Rapoport MJ, McCullagh S, Streiner D, et al. Age and major depression after mild traumatic brain injury. Am J Geriatr Psychiatry. 05–06. 2003;11(3):365-369. [pmid: 12724117].
87 Rapoport MJ, Herrmann N, Shammi P, et al. Outcome after traumatic brain injury sustained in older adulthood: a one-year longitudinal study. Am J Geriatr Psychiatry. 05. 2006;14(5):456-465. [pmid: 16670250].
88 Rapoport MJ, Kiss A, Feinstein A. The impact of major depression on outcome following mild-to-moderate traumatic brain injury in older adults. J Affect Disord. 06. 2006;92(2–3):273-276. [pmid: 16504305].
89 Rapoport M, McCauley S, Levin H, et al. The role of injury severity in neurobehavioral outcome 3 months after traumatic brain injury. Neuropsychiatry Neuropsychol Behav Neurol. 06. 2002;15(2):123-132. [pmid: 12050475].
90 Rapoport MJ, McCullagh S, Streiner D, et al. The clinical significance of major depression following mild traumatic brain injury. Psychosomatics. 01–02. 2003;44(1):31-37. [pmid: 12515835].
91 Rapoport MJ, McCullagh S, Shammi P, et al. Cognitive impairment associated with major depression following mild and moderate traumatic brain injury. J Neuropsychiatry Clin Neurosci. Winter. 2005;17(1):61-65. [pmid: 15746484].
92 Ruocco AC, Swirsky-Sacchetti T, Choca JP. Assessing personality and psychopathology after traumatic brain injury with the Millon Clinical Multiaxial Inventory-III. Brain Inj. 11. 2007;21(12):1233-1244. [pmid: 18236199].
93 Satz P, Zaucha K, Forney DL, et al. Neuropsychological, psychosocial and vocational correlates of the Glasgow Outcome Scale at 6 months post-injury: a study of moderate to severe traumatic brain injury patients. Brain Inj. 07. 1998;12(7):555-567. [pmid: 9653519].
94 Satz P, Forney DL, Zaucha K, et al. Depression, cognition, and functional correlates of recovery outcome after traumatic brain injury. Brain Inj. 07. 1998;12(7):537-553. [pmid: 9653518].
95 Seel RT, Kreutzer JS. Depression assessment after traumatic brain injury: an empirically based classification method. Arch Phys Med Rehabil. 11. 2003;84(11):1621-1628. [pmid: 14639561].
96 Seel RT, Kreutzer JS, Rosenthal M, et al. Depression after traumatic brain injury: a National Institute on Disability and Rehabilitation Research Model Systems multicenter investigation. Arch Phys Med Rehabil. 02. 2003;84(2):177-184. [pmid: 12601647].
97 Sherer M, Evans CC, Leverenz J, et al. Therapeutic alliance in post-acute brain injury rehabilitation: predictors of strength of alliance and impact of alliance on outcome. Brain Inj. 06. 2007;21(7):663-672. [pmid: 17653940].
98 Sherman EM, Strauss E, Slick DJ, et al. Effect of depression on neuropsychological functioning in head injury: measurable but minimal. Brain Inj. 07. 2000;14(7):621-632. [pmid: 10914644].
99 Stalnacke BM. Community integration, social support and life satisfaction in relation to symptoms 3 years after mild traumatic brain injury. Brain Inj. 08. 2007;21(9):933-942. [pmid: 17729046].
100 Tateno A, Jorge RE, Robinson RG. Clinical correlates of aggressive behavior after traumatic brain injury. J Neuropsychiatry Clin Neurosci. Spring. 2003;15(2):155-160. [pmid: 12724455].
101 Whelan-Goodinson R, Ponsford J, Schonberger M. Association between psychiatric state and outcome following traumatic brain injury. J Rehabil Med. 11. 2008;40(10):850-857. [pmid: 19242623].
102 Ashman TA, Cantor JB, Gordon WA, et al. A randomized controlled trial of sertraline for the treatment of depression in persons with traumatic brain injury. Arch Phys Med Rehabil. 05. 2009;90(5):733-740. [pmid: 19406291].
103 American Congress of Rehabilitation Medicine. Definition of mild traumatic brain injury. J Head Trauma Rehabil. 1993;8:86-88.
104 Control NCfIPa. Report to Congress on Mild Traumatic Brain Injury in the United States: Steps to Prevent a Serious Public Health Problem. Atlanta. Centers for Disease Control and Prevention. 2003.
105 Teasdale G, Jennett B. Assessment of coma and impaired consciousness. A practical scale. Lancet. 07. 13. 1974;2(7872):81-84. [pmid: 4136544].
106 Von Holst H, Cassidy JD. Mandate of the WHO Collaborating Centre Task Force on Mild Traumatic Brain Injury. J Rehabil Med. 02. 2004;43(Suppl):8-10. [pmid: 15083866].
107 Wittchen HU. Reliability and validity studies of the WHO--Composite International Diagnostic Interview (CIDI): a critical review. J Psychiatr Res. 01–02. 1994;28(1):57-84. [pmid: 8064641].
108 Lewis G, Araya R. Classification, disability and the public health agenda. Br Med Bull. 2001;57:3-15. [pmid: 11719921].
109 Robins LN, Helzer JE, Croughan J, et al. National Institute of Mental Health Diagnostic Interview Schedule. Its history, characteristics, and validity. Arch Gen Psychiatry. 04. 1981;38(4):381-389. [pmid: 6260053].
110 First MB, Frances A, Pincus HA. DSM-IV-TR Handbook of Differential Diagnois. Arlington, VA. American Psychiatric Publishing, Inc. 2002.
111 Teasdale TW, Christensen AL, Willmes K, et al. Subjective experience in brain-injured patients and their close relatives: a European Brain Injury Questionnaire study. Brain Inj. 08. 1997;11(8):543-563. [pmid: 9251864].
112 Goldberg DP, Hillier VF. A scaled version of the General Health Questionnaire. Psychol Med. 02. 1979;9(1):139-145. [pmid: 424481].
113 Bagby RM, Ryder AG, Schuller DR, et al. The Hamilton Depression Rating Scale: has the gold standard become a lead weight?. Am J Psychiatry. 12. 2004;161(12):2163-2177. [pmid: 15569884].
114 Marsh NV, Kersel DA, Havill JA, et al. Caregiver burden during the year following severe traumatic brain injury. J Clin Exp Neuropsychol. 06. 2002;24(4):434-447. [pmid: 12187457].
115 Snaith RP, Bridge GW, Hamilton M. The Leeds scales for the self-assessment of anxiety and depression. Br J Psychiatry. 02. 1976;128:156-165. [pmid: 942576].
116 Warriner EM, Rourke BP, Velikonja D, et al. Subtypes of emotional and behavioural sequelae in patients with traumatic brain injury. J Clin Exp Neuropsychol. 10. 2003;25(7):904-917. [pmid: 13680439].
117 Malec JF, Testa JA, Rush BK, et al. Self-assessment of impairment, impaired self-awareness, and depression after traumatic brain injury. J Head Trauma Rehabil. 05–06. 2007;22(3):156-166. [pmid: 17510591].
118 Morey LC. Personality Assessment Inventory professional manual. Odessa, FL. Psychological Assessment Resources. 1991.
119 Spitzer RL, Williams JB, Kroenke K, et al. Utility of a new procedure for diagnosing mental disorders in primary care. The PRIME-MD 1000 study. JAMA. 12. 14. 1994;272(22):1749-1756. [pmid: 7966923].
120 Veysey BM, Steadman HJ, Morrissey JP, et al. Using the Referral Decision Scale to screen mentally ill jail detainees: validity and implementation issues. Law Hum Behav. 04. 1998;22(2):205-215. [pmid: 9566122].
121 Smith-Seemiller L, Fow NR, Kant R, et al. Presence of post-concussion syndrome symptoms in patients with chronic pain vs mild traumatic brain injury. Brain Inj. 03. 2003;17(3):199-206. [pmid: 12623496].
122 Wing JK, Babor T, Brugha T, et al. SCAN. Schedules for Clinical Assessment in Neuropsychiatry. Arch Gen Psychiatry. 06. 1990;47(6):589-593. [pmid: 2190539].