# Sample Data Abstraction Forms

Abstract/Title Review Form

Full-text Review Form

Evidence Table (REF ID# )

Study Description | Inclusion/Exclusion Criteria | Population and Baseline Characteristics | Study Definitions | Depression Incidence/Prevalence & Co-morbidities | Quality Rating
Author: Author et al., YYYY Country, Setting: Country, setting Enrollment Period: Design: Time from injury: Length of followup: Dep. Scale/Tool: | Inclusion criteria:; - Inclusion #1; - Inclusion #2; - Inclusion #3; Exclusion criteria:; - Exclusion #1; - Exclusion #2; - Exclusion #3; TBI Def: | Group(s): N screened: N eligible: N included: N at conclusion: Depression: Prior to injury: At time of injury: Other preexisting psychiatric conditions: N with prior TBI (%): Age, yrs ± SD: G1: XX ± ## Age ≥16, N (%): G1: XX (##) Global injury severity (ISS, RTS, etc.): Severity of TBI (GCS): Mechanism/type of injury: Area of brain injured: Concomitant injuries: | Depression: (Starting with most severe) Other co-morbidities: PTSD: Other anxiety disorder: Irritability: Aggression: Suicidality: Substance use: Other psychiatric diagnoses (schizophrenia, psychosis, OCD, etc): Health-related QoL or functional status: | Depression: Taking depression medications (%): Other co-morbidities: PTSD: Other anxiety disorder: Irritability: Aggression: Suicidality: Substance use: Other psychiatric diagnoses: Health-related QoL or functional status:

Criteria for KQ1 Includes

Criteria for KQ2 Includes

Criteria for KQ3 Includes