# Exact Search Strings

PubMed search strategies

Search # | Terms | Retrieval
#1 | (Brain Concussion[mh] OR brain injuries[mh:noexp] OR Brain Hemorrhage, Traumatic[mh] OR Epilepsy, Post-Traumatic[mh] OR Head Injuries, Closed[mh] OR Head Injuries, Penetrating[mh] OR Intracranial Hemorrhage, Traumatic[mh] OR Craniocerebral Trauma[mh] OR TBI[tiab] OR head injuries[tiab] OR head injury[tiab] OR traumatic brain injury[tiab] OR traumatic brain injuries[tiab] OR neurotrauma[tiab] OR diffuse axonal injury[mh] OR diffuse axonal injury[tiab] OR brain trauma[tiab] OR head trauma[tiab]) | 109,710
#2 | Depressive Disorder[mh] OR Depression[mh] OR depressive[tiab] OR depression[tiab] OR depressed[tiab] OR sadness[tiab] OR sad[tiab] OR hopelessness[tiab] OR suicidal[tiab] OR suicide[tiab] OR Mental Disorders[mh:noexp] OR mood[tiab] | 396,835
#3 | #1 AND #2 AND eng[la] AND humans[mh] | 2,388
#4 | #3 AND case reports[pt] | 511
#5 | #3 AND letter[pt] | 38
#6 | #3 AND comment[pt] | 22
#7 | #3 AND editorial[pt] | 13
#8 | #3 AND practice guideline[pt] | 2
#9 | #3 AND news[pt] | 4
#10 | #3 AND review[pt] | 383
#11^*^ | #3 NOT (#4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10) | 1,491^*^

* Numbers do not total due to exclusions in more than one category (12 items were indexed as letter and comment; 2 were case reports, letters, and comments; 17 were case reports and letters; 36 were case reports and reviews; 4 were editorials and comments; 1 was a review and a comment; and 2 were editorials and reviews).

PsycINFO search results

Search # | Terms | Retrieval^*^
#1 | DE=("head injuries" or "brain concussion" or "traumatic brain injury") or KW=("head injury" or "head injuries" or "traumatic brain injury" or "traumatic brain injuries" OR "craniocerebral trauma" or neurotrauma or "brain trauma" OR "head trauma" OR TBI) | 9,647
#2 | DE=("depression emotion" or "major depression" or "hopelessness" or "sadness" or "suicidal ideation" or "suicide") or KW=(depressive or sad or hopeless or sadness) | 107,224
#3 | #1 AND #2 AND LA=(English) AND PO=(Human) | 333^*^
#4 | #3 AND PT=(letter) | 6^*^
#5 | #3 AND PT=(comment/reply) | 6^*^
#6 | #3 AND PT=(editorial) | 2^*^
#10 | #3 NOT (#4 OR #5 OR #6) | 319^*^

* Denotes number of citation retrieved from peer-reviewed journals

Embase search results

Search # | Terms | Retrieval
#1 | head injury/ or brain concussion/ or brain contusion/ or diffuse axonal injury/ or postconcussion syndrome/ or traumatic brain injury/ or ("craniocerebral trauma" or "brain trauma" or "head trauma" or TBI or "traumatic brain injury" or "traumatic head injury" or "traumatic brain injuries" or "traumatic head injuries").ab. or ("craniocerebral trauma" or "brain trauma" or "head trauma" or TBI or "traumatic brain injury" or "traumatic head injury" or "traumatic brain injuries" or "traumatic head injuries").ti. | 12,018
#2 | mental disease/ or mood disorder/ or depression/ or major depression/ or suicidal ideation/ or hopelessness/ or (depressive or sad or sadness or hopeless).ti. or (depressive or sad or sadness or hopeless).ab. | 102,913
#3 | 1 and 2 and english.lg. and human/ | 505
#4 | 3 and conference paper.pt. | 13
#5 | 3 and editorial.pt. | 15
#6 | 3 and letter.pt. | 13
#7 | 3 and note.pt. | 16
#8 | 3 and review.pt. | 221
#9 | 3 and short survey.pt. | 14
#10 | 3 not (4 or 5 or 6 or 7 or 8 or 9) | 213

CINAHL search results

Search # | Terms | Retrieval
S1 | ("traumatic brain injury") or (MH "Brain Injuries+") OR "neurotrauma" OR "brain injuries" OR "TBI" OR "concussion" OR "head injuries" OR "head injury" OR "head trauma" OR "brain trauma" | 14,021
S2 | ((MH "Depression+") OR "depressive disorder" OR "sadness" OR "depressed" OR (MH "Suicide") or (MH "Suicide, Attempted") or (MH "Suicidal Ideation") OR "suicide" OR "hopelessness" or (MH "Hopelessness") OR "mood") | 45,193
S3 | S1 AND S2 AND LA English | 481
S4 | S3 AND Exclude MEDLINE Records | 145
S5 | S4 and PT doctoral dissertation | 18
S6 | S4 and PT commentary | 3
S7 | S4 and PT letter | 2
S8 | S4 and PT systematic review | 1
S9 | S4 and PT review | 11
S10 | S4 and PT audiovisual | 1
S11 | S4 not (S5 OR S6 OR S7 OR S8 OR S9) | 109

PILOTS search results

Search # | Terms | Retrieval
#1 | (DE="head injuries") or ("brain concussion" OR concussion OR "traumatic brain injury" OR "TBI" OR neurotrauma OR "traumatic brain injuries" OR "head trauma" OR "craniocerebral trauma" OR "brain injury" OR "brain injuries" ) | 667
#2 | (DE="depressive disorders") or (depression OR depressed OR depressive OR suicidal OR suicide OR sadness OR hopelessness) | 9,063
#3 | #1 AND #2 AND LA=(English) | 163
#4 | #3, limited to peer-reviewed journals | 116

## Search Strategies

Search strategies for relevant white papers and reports

Resource | Date Searched | # of results | Search Strategy
Google search for .gov sites | 2/2/2010 | 16,300 (examined the first 15 pages of the search) | allintext: (depression OR depressive OR mood) AND ("acquired brain injury" OR "traumatic brain injury" OR TBI OR "head injury" OR neurotrauma OR "head trauma" OR "brain trauma") site:.gov excluded: press release, news, blog posts, PowerPoint, consumer health information
Google search for .mil sites | 2/ 2/2010 | 1,1910 (examined the first 15 pages of the search) | allintext: (depression OR depressive OR mood) AND ("acquired brain injury" OR "traumatic brain injury" OR TBI OR "head injury" OR neurotrauma OR "head trauma" OR "brain trauma") site:.mil excluded: press release, news, blog posts, PowerPoint, consumer health information
Google search for .edu sites | 2/2/2010 | 18,100 (examined the first 15 pages of the search) | allintext: (depression OR depressive OR mood) AND ("acquired brain injury" OR "traumatic brain injury" OR TBI OR "head injury" OR neurotrauma OR "head trauma" OR "brain trauma") site:.edu excluded: press release, news, blog posts, PowerPoint, consumer health information
Google search for .org sites | 2/2/2010 | 119,000 (examined the first 15 pages of the search) | allintext: (depression OR depressive OR mood) AND ("acquired brain injury" OR "traumatic brain injury" OR TBI OR "head injury" OR neurotrauma OR "head trauma" OR "brain trauma") site:.org excluded: press release, news, blog posts, PowerPoint, consumer health information

Search strategies for relevant clinical trials and government funding

Resource | Date Searched | # of results | Search Strategy
Clinicaltrials.gov | 2/2/2010 | 53 | ("traumatic brain injury" OR "traumatic head injury" OR "head injury" OR TBI OR "craniocerebral trauma" OR "brain trauma" OR neurotrauma OR "head trauma") AND (depressed OR depression OR depressive OR "Depressive Disorder" OR "mood disorder")
NIH RePORTER | 2/2/2010 | 47 | “traumatic brain injury” depression Limited: current projects
NIH RePORTER | 2/2/2010 | 13 | “traumatic brain injury” mood Limited: current projects
NIH RePORTER | 2/2/2010 | -- | Other term combinations did not retrieve any unique results (tested terms include TBI, brain trauma, head trauma)
National Rehabilitation Information Center (NARIC) | 2/2/2010 | 18 | Search #1: “Brain injury” depression Limited to Ongoing projects Inclusion of mood, depressed, or depressive did not retrieve anymore relevant articles
International Clinical Registries (WHO) | 2/2/2010 | 236 | Traumatic AND brain AND injury Limited to results to registries other than Clinicaltrials.gov Inclusion of mood, depression, depressed, or depressive did not retrieve any unique articles
Grants.gov | 2/2/2010 | 48 | TBI depression
Grants.gov | 2/2/2010 | 26 | TBI psycholog^*^ Inclusion of “traumatic brain injury”, mood, depressed, or depressive did not retrieve any unique articles

Search strategies for relevant conference proceedings

Resource | Date Searched | # of results | Search Strategy
BIOSIS | 2/2/2010 | 117 | TS=(depression OR depressive OR mood) AND TS=("acquired brain injury" OR "traumatic brain injury" OR TBI OR "head injury" OR neurotrauma OR "head trauma" OR "brain trauma"), Limits: Language=(English), Document Type=(Meeting OR Meeting Paper OR Technical Report OR Thesis Dissertation)
PsycInfo | 2/2/2010 | 59 | (DE=("head injuries" or "brain concussion" or "traumatic brain injury") or KW=("head injury" or "head injuries" or "traumatic brain injury" or "traumatic brain injuries" OR "craniocerebral trauma" or neurotrauma or "brain trauma" OR "head trauma" OR TBI)) and (DE=("depression emotion" or "major depression" or "hopelessness" or "sadness" or "suicidal ideation" or "suicide") or KW=(depressive or sad or hopeless or sadness)) AND (PT=(dissertation) or PT=(conference proceedings) or PT=(dissertation abstract))

Resources that retrieved redundant information or did not retrieve relevant information

Resource | Date Searched
- DeployMed Research Link (DoD-funded research); - Defense centers of excellence; - Australian/New Zealand Clinical Trials Registry; - PsiTri (Mental Health Registry); - Current Controlled Trials (UK); - PapersFirst; - Sociological Abstracts | February 2, 2010