# Apppendixes

Appendix A Exact Search Strings

Appendix B Sample Data Abstraction Forms

Appendix C Evidence Tables

Appendix D Excluded Studies

Appendix E Peer Reviewers

Appendix F Grey Literature Results