# Acknowledgments

We are indebted to an extraordinary team for their work on this report. Specifically, Cheena Clermont calculated weighted averages of prevalence and developed the data displays and analyses critical to our ability to answer Key Questions 1 and 2. Her quantitative skills and ability to translate complex concepts into clear presentations are an enormous benefit.

Ellen Davis tirelessly assisted with coordination of meetings and sorting and evaluating publications. We appreciate her daily for her enthusiasm, energy, and grace under pressure.

Mark Hartmann is our technical editor, without whom our evidence tables would not be nearly as consistent. His eye for detail and ability to review a profusion of data and tables is essential.

Michael Tranchina and Rachel Bazan spent hours as our work study students tracking and organizing hundreds of documents for this review. We are grateful for their consistency, positive attitude, and efficiency.