# Acronyms/Abbreviations

[la]/LA: Language
[mh:noexp]: does not include MeSH terms found below this term in the MeSH tree
[mh]: Medical Subject Heading
[pt]/PT: Publication type
[tw]: Text word
ab.: Abstract word
ABI: Acquired Brain Injury
AES-S: Apathy Evaluation Scale-Self Rated
AUDIT: Alcohol Use Disorders Identification Test
BDI: Beck Depression Inventory
BHS: Becks Hopelessness Scale
BIS: Brain Injury Scale
BSI: Brief Symptom Inventory
CAQ: Clinical Analysis Questionnaire
CES-D: Center for Epidemiologic Studies Depression Scale
CHI: Closed head injury
CIDI: Composite International Diagnostic Interview
CiOP: Changes in Outlook Questionnaire
CIQ: Community Integration Questionnaire
CIRS: Cumulative Illness Rating Scale
CIS-R: Clinical Interview Schedule-Revised
CNS: Central nervous system
COF: Causes of Fatigue Questionnaire
COS: Community Outcome Scale
CPCS: Checklist of Postconcussion Symptoms
CT: Computed tomography
DASS: Depression Anxiety Stress Scales
DAST: Drug Abuse Screening Test
DE: Descriptors/Descriptors assigned to citations
DIS-III-A: The Diagnostic Interview Schedule Version A
DSM-IV: Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition
EBIQ: European Brain Injury Questionnaire
FAM: Functional Assessment Measure
FIM: Functional Independence Measure
FSS: Fatigue Severity Scale
GAF: Global Assessment of Functioning
GCS: Glasgow Coma Scale
GHQ: General Health Questionnaire
GOS: Glasgow Outcome Scale
GOS-E: Glasgow Outcome Scale Extended
GSW: Gunshot wound(s)
HADS: Hospital Anxiety and Depression Scale
HAM-D: Hamilton Rating Scale for Depression
HAS: Hamilton Anxiety Scale
HIBS: Head Injury Behavior Rating Scale
HSCL-25: Hopkins Symptom Checklist
HTQ: Harvard Trauma Questionnaire
ICD-10: International Classification of Diseases version 10
IDPESQ: Indice de detresse psychologique de l’Enquete Sante Quebec (French adaptation of the Psychiatric Symptom Index)
ISS: Injury Severity Scale
K-10: Kessler Psychological Distress Scale
kw/KW: Key words
Lg.: language
LOC: Loss of Consciousness
LSI-A: Life Satisfaction Index I-A
MADRS: Montgomery and Asberg Depression Rating Scale
MASQ: Mood and Anxiety Symptom Questionnaire—Short Form
MCMI-II/III: Millon Clinical Multi-Axial Inventory (version 2/3)
MDE: Major depressive episode(s)
MeSH: Medical Subject Heading
mg/dL: Milligram per deciliter
MMPI-2: Minnesota Multiphasic Personality Inventory version 2
MPAI: Mayo-Portland Adaptability Inventory
NEOPI-R: NEO Personality Inventory-Revised
NFI-Dep: Neurobehavioral Functioning Index Depression Subscale
NPI: Neuropsychiatric Inventory
NRS-R: Neurobehavioral Rating Scale-Revised
PAI: Personality Assessment Inventory
PCS: Postconcussion Syndrome
PHQ-9: Patient Health Questionnaire-9
PIM: Participation and Independence Measure
PO: population
POMS: Profile of Mood States
PRIME-MD: Primary Care Evaluation of Mental Disorders
PSE: Present State Examination
PSS: Perceived Stress Scale
PTA: Post-traumatic Amnesia
QoL: Quality of life
RDS: Referral Decision Scale
RPCQ: Rivermead Post-Concussion Disorder Questionnaire
SCAN: Schedules for Clinical Assessment in Neuropsychiatry
SCID: Structured Clinical Interview for DSM-IV
SCL 90: Symptom Checklist 90
SCL-20: Hopkins Symptom Checklist depression subscale
SF-12 v2: 12-Item Short Form Health Survey-Version 2
SF-36: 36-Item Short Form Survey Instrument
SIP: Sickness Impact Profile
TBI: Traumatic Brain Injury
ti.: Title word
VAS-D: Visual Analog Scale - Depression
VAS-F: Visual Analog Scale - Fatigue
WHOQOL-BREF: World Health Organization Quality of Life Questionnaire
WSRS: Wimbledon Self-Report Scale
ZDS: Zung Depression Scale
ZSDS: Zung Self-rating Depression Scale