# References

1 Helfand M. Screening for Thyroid Disease. Systematic Evidence Review No 23. (Prepared by the Oregon Health & Science University Evidence-based Practice Center under Contract No 290-97-0018). 2004. January. Rockville, MD. Agency for Healthcare Research and Quality.
2 Helfand M. Screening for subclinical thyroid dysfunction in nonpregnant adults: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. Jan. 20. 2004;140(2):128-141. [pmid: 14734337].
3 Jameson J. Chapter 335 Disorders of the Thyroid Gland. Fauci A, Braunwald E, Kasper D, Houser S, Longo D, Jameson J, editors. Harrison's Principles of Internal Medicine. New York. The McGraw-Hill Companies, Inc. 2008:2224-2246.
4 Surks MI, Goswami G, Daniels GH. The Thyrotropin Reference Range Should Remain Unchanged. J Clin Endocrinol Metab. Sep. 1. 2005;90(9):5489-5496. [pmid: 16148346].
5 Cooper DS. Clinical Practice: Subclinical Hypothyroidism. N Engl J Med. Jul. 26. 2001;345(4):260-265. [pmid: 11474665].
6 Parle JV, Franklyn JA, Cross KW, et al. Assessment of a screening process to detect patients aged 60 years and over at high risk of hypothyroidism. Br J Gen Pract. Oct. 1991;41(351):414-416. [pmid: 1777296].
7 Canaris GJ, Manowitz NR, Mayor G, et al. The Colorado Thyroid Disease Prevalence Study. Arch Intern Med. 2000;160(4):526-534. [pmid: 10695693].
8 Lindeman RD, Schade DS, LaRue A, et al. Subclinical hypothyroidism in a biethnic, urban community. Journal of the American Geriatrics Society. 1999;47(6):703-709. [pmid: 10366170].
9 Helfand M, Redfern CC. Clinical guideline, part 2. Screening for thyroid disease: an update. American College of Physicians. Ann Intern Med. Jul. 1998;21:144-158. [pmid: 9669977].
10 Helfand M, Redfern CC. Screening for Thyroid Disease: An Update. Annals of Internal Medicine. 1998;129(2):144-158. [pmid: 9669977].
11 Cooper D, Halpern RF, Wood L, et al. L-Thyroxine therapy in subclinical hypothyroidism. A double-blind, placebo-controlled trial. Ann Intern Med. 1984;101(1):18-24. [pmid: 6428290].
12 Biondi B, Cooper DS. The Clinical Significance of Subclinical Thyroid Dysfunction. Endocr Rev. Feb. 1. 2008;29(1):76-131. [pmid: 17991805].
13 Waise A, Price HC. The upper limit of the reference range for thyroid-stimulating hormone should not be confused with a cut-off to define subclinical hypothyroidism. Ann Clin Biochem. Mar. 1. 2009;46(2):93-98. [pmid: 19164339].
14 Wartofsky L, Dickey RA. The Evidence for a Narrower Thyrotropin Reference Range Is Compelling. J Clin Endocrinol Metab. Sep. 1. 2005;90(9):5483-5488. [pmid: 16148345].
15 Walsh JP, Bremner AP, Feddema P, et al. Thyrotropin and Thyroid Antibodies as Predictors of Hypothyroidism: A 13-Year, Longitudinal Study of a Community-Based Cohort Using Current Immunoassay Techniques. J Clin Endocrinol Metab. Mar. 1. 2010;95(3):1095-1104. [pmid: 20097710].
16 Klubo-Gwiezdzinska J, Wartofsky L. Thyrotropin Blood Levels, Subclinical Hypothyroidism, and the Elderly Patient. Arch Intern Med. Nov. 23. 2009;169(21):1949-1951. [pmid: 19933954].
17 Helfand M. Appendix B Screening for thyroid disease: systematic evidence Review. Stone M, Wallace R, editors. Medicare coverage of routine screening for thyroid dysfunction. Natl Academy Press. 2003:75-113.
18 Surks MI, Boucai L. Age-and Race-Based Serum Thyrotropin Reference Limits. J Clin Endocrinol Metab. Feb. 1. 2010;95(2):496-502. [pmid: 19965925].
19 McDermott MT, Ridgway EC. Subclinical Hypothyroidism Is Mild Thyroid Failure and Should be Treated. J Clin Endocrinol Metab. Oct. 1. 2001;86(10):4585-4590. [pmid: 11600507].
20 Vanderpump MPJ, Tunbrldge WMG, French JM, et al. The incidence of thyroid disorders in the community: a twenty-year follow-up of the Whickham Survey. Clinical Endocrinology. 1995;43(1):55-68. [pmid: 7641412].
21 Surks MI, Ortiz E, Daniels GH, et al. Subclinical thyroid disease: scientific review and guidelines for diagnosis and management. JAMA. Jan. 14. 2004;291(2):228-238. [pmid: 14722150].
22 Hollowell JG, Staehling NW, Flanders WD, et al. Serum TSH, T4, and Thyroid Antibodies in the United States Population (1988 to 1994): National Health and Nutrition Examination Survey (NHANES III). J Clin Endocrinol Metab. Feb. 1. 2002;87(2):489-499. [pmid: 11836274].
23 Tunbridge WM, Evered DC, Hall R, et al. The spectrum of thyroid disease in a community: the Whickham survey. Clin Endocrinol (Oxf). Dec. 1977;7(6):481-493. [pmid: 598014].
24 Eddy D. How to think about screening. Common Screening Tests Philadelphia. American Coll Physicians. 1991:1-21.
25 Joffe RT, Brimacombe M, Levitt AJ, et al. Treatment of Clinical Hypothyroidism With Thyroxine and Triiodothyronine: A Literature Review and Metaanalysis. Psychosomatics. Oct. 1. 2007;48(5):379-384. [pmid: 17878495].
26 Beastall G, Beckett G, Franklyn J, et al. UK Guidelines for the Use of Thyroid Function Tests. 2006.
27 Fatourechi V, Lankarani M, Schryver PG, et al. Factors Influencing Clinical Decisions to Initiate Thyroxine Therapy for Patients With Mildly Increased Serum Thyrotropin (5.1-10.0 mIU/L). Mayo Clinic Proceedings. May. 2003;78(5):554-560. [pmid: 12744541].
28 Shrier DK, D BK. Subclinical hyperthyroidism: controversies in management. Am Fam Physician. 2002;65(3):431-438. [pmid: 11858626].
29 Gharib H, Cobin RH, Dickey RA. Subclinical hypothyroidism during pregnancy: position statement from the American Association of Clinical Endocrinologists. Endocr Pract. 1999;5(6):367-368.
30 Ladenson PW, Singer PA, Ain KB, et al. American Thyroid Association guidelines for detection of thyroid dysfunction. Archives of Internal Medicine. 2000;160(11):1573. [pmid: 10847249].
31 Stone M, Wallace R, editors. Medicare coverage of routine screening for thyroid dysfunction. 2003. Natl Academy Press.
32 Screening for Thyroid Disease: Recommendation Statement. Annals of Internal Medicine. Jan. 2004. 2004;140(2):125-127. [pmid: 14734336].
33 Quan ML, Pasieka JL, Rorstad O. Bone mineral density in well-differentiated thyroid cancer patients treated with suppressive thyroxine: a systematic overview of the literature. J Surg Oncol. Jan. 5. 2002:62-69. discussion 9-70.
34 Gharib H, Tuttle R, Baskin H, et al. Consensus statement: subclinical thyroid dysfunction: a joint statement on management from the American Association of Clinical Endocrinologists, the American Thyroid Association, and the Endocrine Society. Journal of Clinical Endocrinology & Metabolism. 2005;90(1):581-585. [pmid: 15643019].
35 Demers C, Spencer C. National Academy of Clinical Biochemistry Laboratory support for the diagnosis and monitoring of thyroid disease. 2002.
36 ACOG Committee Opinion No. 381: Subclinical hypothyroidism in pregnancy. Obstet Gynecol. 2007;110(4):959-960. [pmid: 17906045].
37 Helfand M, Crapo LM. Testing for suspected thyroid disease. HC S, editor. Common Diagnostic Tests. Philadelphia. American College of Physicians. 1990:148-182.
38 Hak AE, Pols HAP, Visser TJ, et al. Subclinical Hypothyroidism Is an Independent Risk Factor for Atherosclerosis and Myocardial Infarction in Elderly Women: The Rotterdam Study. Annals of Internal Medicine. 2000;132(4):270-278. [pmid: 10681281].
39 Walsh JP, Bremner AP, Bulsara MK, et al. Subclinical thyroid dysfunction as a risk factor for cardiovascular disease. Arch Intern Med. Nov. 28. 2005. 2005;165(21):2467-2472. [pmid: 16314542].
40 Cappola AR, Fried LP, Arnold AM, et al. Thyroid status, cardiovascular risk, and mortality in older adults. JAMA. Mar. 1. 2006;295(9):1033-1041. [pmid: 16507804].
41 Rodondi N, Newman AB, Vittinghoff E, et al. Subclinical hypothyroidism and the risk of heart failure, other cardiovascular events, and death. Arch Intern Med. Nov. 28. 2005;165(21):2460-2466. [pmid: 16314541].
42 Imaizumi M, Akahoshi M, Ichimaru S, et al. Risk for ischemic heart disease and all-cause mortality in subclinical hypothyroidism. J Clin Endocrinol Metab. Jul. 2004;89(7):3365-3370. [pmid: 15240616].
43 Singh S, Duggal J, Molnar J, et al. Impact of subclinical thyroid disorders on coronary heart disease, cardiovascular and all-cause mortality: A meta-analysis. International Journal of Cardiology. 2008;125(1):41-48. [pmid: 17434631].
44 Volzke H, Schwahn C, Wallaschofski H, et al. The Association of Thyroid Dysfunction with All-Cause and Circulatory Mortality: Is There a Causal Relationship?. J Clin Endocrinol Metab. July. 1. 2007;92(7):2421-2429. [pmid: 17473067].
45 Ochs N, Auer R, Bauer DC, et al. Meta-analysis: subclinical thyroid dysfunction and the risk for coronary heart disease and mortality. Ann Intern Med. Jun. 3. 2008;148(11):832-845. [pmid: 18490668].
46 Razvi S, Shakoor A, Vanderpump M, et al. The influence of age on the relationship between subclinical hypothyroidism and ischemic heart disease: a metaanalysis. J Clin Endocrinol Metab. Aug. 1. 2008;93(8):2998-3007. [pmid: 18505765].
47 Razvi S, Weaver JU, Vanderpump MP, et al. The incidence of ischemic heart disease and mortality in people with subclinical hypothyroidism: reanalysis of the Whickham Survey cohort. J Clin Endocrinol Metab. Feb. 2010;13:1734-1740. [pmid: 20150579].
48 Vanderpump MPJ, Tunbridge WMG, French JM, et al. The development of ischemic heart disease in relation to autoimmune thyroid disease in a 20-year follow-up study of an English community. Thyroid. 1996;6(3):155-160. [pmid: 8837320].
49 Alevizaki M, Saltiki K, Voidonikola P, et al. Free thyroxine is an independent predictor of subcutaneous fat in euthyroid individuals. Eur J Endocrinol. 2009;161(3):459-465. [pmid: 19700640].
50 Ruhla S, Weickert MO, Arafat AM, et al. A high normal TSH is associated with the metabolic syndrome. Clinical Endocrinology. 2010;72(5):696-701. [pmid: 20447068].
51 Rodondi N, Bauer DC, Cappola AR, et al. Subclinical Thyroid Dysfunction, Cardiac Function, and the Risk of Heart Failure: The Cardiovascular Health Study. Journal of the American College of Cardiology. 2008;52(14):1152-1159. [pmid: 18804743].
52 Rosario PW. Natural history of subclinical hyperthyroidism in elderly patients with TSH between 0· 1 and 0·4 mIU/l: a prospective study. Clinical Endocrinology. 2010;72(5):685-688. [pmid: 20447066].
53 Whitlock EP, Lopez SA, Chang S, et al. Identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the Effective Health Care program. Journal of Clinical Epidemiology. 2009. In Press, Corrected Proof.
54 U.S. Preventive Service Task Force Procedure Manual. AHRQ Publication No. 08-05118-EF. Rockville, MD. Agency for Healthcare Research and Quality. July. 2008. Contract No.: January 6th.
55 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
56 Baskin HJ, Cobin RH, Duick DS, et al. American Association of Clinical Endocrinologists medical guidelines for clinical practice for the evaluation and treatment of hyperthyroidism and hypothyroidism. Endocr Pract. Nov-Dec. 2002;8(6):457-469. [pmid: 15260011].
57 Lindstedt G, Eliasson M. [Insufficient evidence for the need of screening and treatment of subclinical thyroid function disorders. Evidence-based analysis]. Lakartidningen. Feb. 2005;15:30-35. [pmid: 15707104].
58 Palmieri EA, Fazio S, Lombardi G, et al. Subclinical hypothyroidism and cardiovascular risk: a reason to treat?. Treat Endocrinol. Jul. 2005;20:233-244.
59 Pham CB, Shaughnessy AF. Should we treat subclinical hypothyroidism?. BMJ. 2008;337:a834. [pmid: 18632678].
60 Bjorndal MM, Sandmo Wilhelmsen K, Lu T, et al. Prevalence and causes of undiagnosed hyperthyroidismin an adult healthy population. The Tromso study. J Endocrinol Invest. Dec. 2008;19:856-860. [pmid: 19092288].
61 Nygaard B. Hyperthyroidism (primary). Clin Evid (Online). 2008. Jan. 1.
62 Faber J, Galloe AM. Changes in bone mass during prolonged subclinical hyperthyroidism due to L-thyroxine treatment: a meta-analysis. Eur J Endocrinol. Apr. 1994;130(4):350-356. [pmid: 8162163].
63 Uzzan B, Campos J, Cucherat M, et al. Effects on bone mass of long term treatment with thyroid hormones: a meta-analysis. J Clin Endocrinol Metab. Dec. 1. 1996;81(12):4278-4289. [pmid: 8954028].
64 Villar HC, Saconato H, Valente O, et al. Thyroid hormone replacement for subclinical hypothyroidism. Cochrane Database of Systematic Reviews. 2007. Issue 3. Art. No.: CD003419. [doi: 10.1002/14651858.CD003419.pub2].
65 Danese MD, Ladenson PW, Meinert CL, et al. Clinical Review 115: Effect of Thyroxine Therapy on Serum Lipoproteins in Patients with Mild Thyroid Failure: A Quantitative Review of the Literature. J Clin Endocrinol Metab. Sep. 1. 2000;85(9):2993-3001. [pmid: 10999775].
66 Peng L, Gu M-J. [Influence of thyroxine treatment on serum lipid levels in patients with subclinical hypothyroidism: A meta-analysis]. Academic Journal of Second Military Medical University. 2007;28(5):519-523.
67 Tanis B, GJ W, HM S. Effect of thyroid substitution on hypercholesterolaemia in patients with subclinical hypothyroidism: a reanalysis of intervention studies. Clin Endocrinol (Oxf). 1996;44(6):643-649. [pmid: 8759176].
68 Nyström E, Caidahl K, Fager G, et al. A double-blind cross-over 12-month study of l-thyroxine treatment of women with 'subclinical' hypothyroidism. Clinical Endocrinology. 1988:63-76.
69 Ross DS, Daniels GH, Gouveia D. The Use and Limitations of a Chemiluminescent Thyrotropin Assay as a Single Thyroid Function Test in an Out-Patient Endocrine Clinic. J Clin Endocrinol Metab. 1990;71(3):764-769. [pmid: 2394778].
70 Jaeschke R, Guyatt G, Gerstein H, et al. Does treatment with l-thyroxine influence health status in middle-aged and older adults with subclinical hypothyroidism?. Journal of General Internal Medicine. 1996;11(12):744-749. [pmid: 9016421].
71 Michalopoulou G, Alevizaki M, Piperingos G, et al. High serum cholesterol levels in persons with 'high-normal' TSH levels: should one extend the definition of subclinical hypothyroidism?. Eur J Endocrinol. Feb. 1. 1998;138(2):141-145. [pmid: 9506856].
72 Meier C, Staub J-J, Roth C-B, et al. TSH-Controlled L-Thyroxine Therapy Reduces Cholesterol Levels and Clinical Symptoms in Subclinical Hypothyroidism: A Double Blind, Placebo-Controlled Trial (Basel Thyroid Study). J Clin Endocrinol Metab. Oct. 1. 2001;86(10):4860-4866. [pmid: 11600554].
73 Monzani F, Di Bello V, Caraccio N, et al. Effect of Levothyroxine on Cardiac Function and Structure in Subclinical Hypothyroidism: A Double Blind, Placebo-Controlled Study. J Clin Endocrinol Metab. 2001;86(3):1110-1115. [pmid: 11238494].
74 Pollock MA, Sturrock A, Marshall K, et al. Thyroxine treatment in patients with symptoms of hypothyroidism but thyroid function tests within the reference range: randomised double blind placebo controlled crossover trial. BMJ. Oct. 20. 2001;323(7318):891-895. [pmid: 11668132].
75 Caraccio N, Ferrannini E, Monzani F. Lipoprotein profile in subclinical hypothyroidism: response to levothyroxine replacement, a randomized placebo-controlled study. J Clin Endocrinol Metab. Apr. 2002;87(4):1533-1538. [pmid: 11932277].
76 Kong WM, Sheikh MH, Lumb PJ, et al. A 6-month randomized trial of thyroxine treatment in women with mild subclinical hypothyroidism. Am J Med. Apr. 1. 2002;112(5):348-354. [pmid: 11904108].
77 Yonem O, Dokmetas HS, Aslan SM, et al. Is antithyroid treatment really relevant for young patients with subclinical hyperthyroidism?. Endocrine Journal. [Clinical Trial Randomized Controlled Trial]. Jun. 2002;49(3):307-314. [pmid: 12201213].
78 Monzani F, Caraccio N, Kozakowa M, et al. Effect of levothyroxine replacement on lipid profile and intima-media thickness in subclinical hypothyroidism: a double-blind, placebo-controlled study. J Clin Endocrinol Metab. May. 2004;89(5):2099-2106. [pmid: 15126526].
79 Yazici M, Gorgulu S, Sertbas Y, et al. Effects of thyroxin therapy on cardiac function in patients with subclinical hypothyroidism: index of myocardial performance in the evaluation of left ventricular function. Int J Cardiol. Jun. 2004;95(2-3):135-143. [pmid: 15193811].
80 Caraccio N, Natali A, Sironi A, et al. Muscle metabolism and exercise tolerance in subclinical hypothyroidism: a controlled trial of levothyroxine. J Clin Endocrinol Metab. Jul. 2005;90(7):4057-4062. [pmid: 15855263].
81 Iqbal A, Jorde R, Figenschau Y. Serum lipid levels in relation to serum thyroid-stimulating hormone and the effect of thyroxine treatment on serum lipid levels in subjects with subclinical hypothyroidism: the Tromso Study. J Intern Med. Jul. 2006;260(1):53-61. [pmid: 16789979].
82 Jorde R, Waterloo K, Storhaug H, et al. Neuropsychological function and symptoms in subjects with subclinical hypothyroidism and the effect of thyroxine treatment. J Clin Endocrinol Metab. Jan. 2006;91(1):145-153. [pmid: 16263815].
83 Buscemi S, Verga S, Cottone S, et al. Favorable clinical heart and bone effects of anti-thyroid drug therapy in endogenous subclinical hyperthyroidism. J Endocrinol Invest. Mar. 2007;30(3):230-235. [pmid: 17505157].
84 Razvi S, Ingoe L, Keeka G, et al. The beneficial effect of L-thyroxine on cardiovascular risk factors, endothelial function, and quality of life in subclinical hypothyroidism: randomized, crossover trial. J Clin Endocrinol Metab. May. 2007;92(5):1715-1723. [pmid: 17299073].
85 Mikhail GS, Alshammari SM, Alenezi MY, et al. Increased atherogenic low-density lipoprotein cholesterol in untreated subclinical hypothyroidism. Endocr Pract. Jul-Aug. 2008;14(5):570-575. [pmid: 18753099].
86 Nagasaki T, Inaba M, Yamada S, et al. Decrease of brachial-ankle pulse wave velocity in female subclinical hypothyroid patients during normalization of thyroid function: a double-blind, placebo-controlled study. Eur J Endocrinol. Mar. 2009;160(3):409-415. [pmid: 19114542].
87 Gussekloo J, van Exel E, de Craen AJ, et al. Thyroid status, disability and cognitive function, and survival in old age. JAMA. Dec. 1. 2004;292(21):2591-2599. [pmid: 15572717].
88 Diez JJ, Iglesias P. Spontaneous Subclinical Hypothyroidism in Patients Older than 55 Years: An Analysis of Natural Course and Risk Factors for the Development of Overt Thyroid Failure. J Clin Endocrinol Metab. Oct. 1. 2004;89(10):4890-4897. [pmid: 15472181].
89 Sawin CT, Geller A, Wolf PA, et al. Low serum thyrotropin concentrations as a risk factor for atrial fibrillation in older persons. N Engl J Med. Nov. 10. 1994;331(19):1249-1252. [pmid: 7935681].
90 Atzmon G, Barzilai N, Hollowell JG, et al. Extreme longevity is associated with increased serum thyrotropin. J Clin Endocrinol Metab. Apr. 1. 2009;94(4):1251-1254. [pmid: 19158193].
91 Simonsick EM, Newman AB, Ferrucci L, et al. Subclinical Hypothyroidism and Functional Mobility in Older Adults. Arch Intern Med. Nov. 23. 2009;169(21):2011-2017. [pmid: 19933964].