# Methods

## Topic Development

This topic was nominated by the public as part of AHRQ’s EHC Program. The USPSTF also expressed interest in updating its 2004 recommendations. We received initial key questions and an analytic framework from AHRQ.Using the methods of the EHC Program53 and the USPSTF54 and with members of the USPSTF, external technical experts, and AHRQ staff, we developed a revised analytic framework and key questions to guide our literature search and review. We sought input from a representative of the nominating organization, experts in thyroid disease, and members of the USPSTF to refine the clinical logic and PICOTS (Population, Intervention, Comparators, Outcome, Timing, and Setting) and to understand the rationale for screening. Draft key questions were posted for public comment on the EHC Program Web site. The final stage in topic development was the approval of the scope and key questions for the report by AHRQ personnel.

## Search Strategy

A research librarian searched MEDLINE, the Cochrane Register Database of Systematic Reviews, and the Database of Abstracts of Reviews of Effects to identify systematic reviews regarding screening and treatment of subclinical hypothyroidism or subclinical hyperthyroidism, with no limits on dates (search strategies are described in Appendix B). As described in detail below, the systematic reviews we identified examined all relevant studies published prior to 2004. Therefore, we searched MEDLINE, AGELINE (AARP.org), EMBASE (embase.com) and the Cochrane Central Register of Controlled Trials to identify studies regarding screening and treatment of subclinical hypothyroidism or subclinical hyperthyroidism published from 2002 (thereby allowing an overlap with all previous reviews) to May 2010. In addition to searching bibliographic databases, we sought additional materials by searching for regulatory information, clinical trial registries, conference proceedings, and other sources of grey literature. Additional studies were identified from citations in relevant articles, discussions with experts, and requests to pharmaceutical companies.

We also performed a supplementary search of bibliographic databases that have a higher concentration of non-English language articles. For this search, we included CINAHL and the World Health Organization (WHO) Global Health Library, which includes African Index Medicus, Index Medicus for the Eastern Mediterranean Region, Latin American and Caribbean Health Sciences Literature, Pan American Health Organization Database, WHO Library Database, and WHO Western Pacific Region Database.

## Selection of Systematic Reviews

The key questions and methods used in the 2004 systematic review by Helfand are similar to those for this report. A search for additional systematic reviews was conducted to ensure that the relevant literature included was comprehensive.

Two reviewers evaluated each review at the title/abstract and full-text article stages to determine eligibility for inclusion. Only reviews that (1) included studies of screening and treatment for subclinical thyroid dysfunction in asymptomatic individuals, (2) included studies that met the design and quality criteria of this current study, and (3) considered outcomes included in the analytic framework of the current study were included.

## Data Abstraction and Quality Rating of Systematic Reviews

Data from the included systematic reviews (Table 4) were abstracted according to the guidance provided in the chapter on “Using Existing Systematic Reviews to Replace de Novo Processes in CERs” from the AHRQ EHC Program Methods Guide for Effectiveness and Comparative Effectiveness Reviews available at: http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318

Table 4 Included systematic reviews

Author Year; N studies | Study types, N | Total participants | SR assessment of quality of primary literature | Overlapping studies N^b,c^ | Quality of SR | Comments
Helfand 2004; 8 | RCT, 8; Metaanalysis of observational studies, 2 | RCT, 291^a^ | Screening Benefits: NA Screening Harms: Poor Yield: Good Treatment Benefits: Poor Treatment Harms Osteoporosis: Good Overtreatment: Good Other: Poor | Villar: 6 Surks: 7 | AMSTAR 9/11
Surks 2004; 23 | RCT, 7; CCT, 15; Observational studies, 1; Meta-analysis, 1 | RCT, 301; CCT, 442; Obs, 21; Meta, 13 studies, 248 patients | NA | Helfand: 7 Villar: 7 | AMSTAR 3/11
Villar 2007; 12 | RCT, 12 | RCT, 461+ | Maximum Jadad score of 5; median score of 12 studies was 4 with a range of 3 to 5 | Helfand: 6 Surks: 7 | AMSTAR 10/11 | Assessed the quality of the individual studies using the Jadad and Schulz criteria, but did not assess the overall strength of the evidence of the body of literature

Abbreviations: AMSTAR=Assessment of Multiple Systematic Reviews; CCT=controlled clinical trial; NA=not applicable; RCT=randomized controlled trial; SR=systematic review.

a One study did not report N.

b Two studies (Cooper 1984; Jaeschke 1996) were common to all three reviews.

c See Table 6 Study Concordance for details.

Abstracted data includes the author and year of the review; the number of included studies and their type (RCT, observational, etc.); total study participants; the reviews assessment of the quality of the body of evidence if available; the overlap of studies among the reviews; and the quality of the systematic review. The quality of each study was assessed using the AMSTAR measurement tool.55

## Individual Study Selection

Two reviewers evaluated each study at the title/abstract and full-text article stages to determine eligibility for inclusion. Studies that included patients with Hashimoto’s disease were included if those patients were asymptomatic and likely were diagnosed as a result of screening for antibodies during the study. Because few studies included patients identified through screening in primary care settings, we included studies of patients from endocrine clinics and from laboratory database studies in which testing of thyroid function was done for a variety of reasons.

The types of studies included and excluded were different for the various key questions (Table 5). For Key Question 1 we included RCTs and observational studies of screening or case-finding for subclinical thyroid dysfunction. For Key Question 2 we did not restrict our search to any particular study design but searched for any harms, including those related to treatment as well as those related to patient issues and concerns about testing, screening, or case finding for subclinical thyroid dysfunction. For Key Question 3, we restricted our search to RCTs of treatment for subclinical hypothyroidism. However, because of the paucity of studies, in addition to RCTs, we included controlled trials, cohort studies, case-control, or other studies that looked at treatment of subclinical hyperthyroidism. For Key Question 4 we again did not restrict our search to any particular study design but searched for any articles reporting harms due to treatment for subclinical hypothyroidism or subclinical hyperthyroidism, including RCTs, controlled trials, cohort studies, and case-control studies.

Table 5 Criteria for inclusion/exclusion of studies in the review

Key Question | RCT | Controlled Trials | Cohort Studies | Case-control Studies | Observational Databases
1a and 1b | √ | | | | √
2 | √ | √ | √ | √ | √
3 | √ | √ | √ | √
4 | √ | √ | √ | √ | √

Abbreviation: RCT=randomized controlled trial.

A discussion of the costs or cost effectiveness of screening was not within the scope of this review. The target population was community living adults, representative of primary care settings. Hospitalized or recently hospitalized participants without history of thyroid disease or symptoms of overt hypothyroidism or hyperthyroidism were excluded as these individuals may have elevated TSH levels. Publications from 2002 to the present were included in the study. This start date was chosen to provide a small period of overlap with the publication date range used in the most recent AHRQ review (Helfand 2004). Non-English language studies were considered for inclusion in the review.

## Data Abstraction and Quality Rating of Individual Studies

We abstracted details about the patient population, study design, data analysis, and results. One author abstracted data and another author verified data abstraction for accuracy. We used predefined criteria developed by the USPSTF to assess the internal validity (quality) of studies (Appendix C). Two authors independently rated the internal validity of each study as “good,” “fair,” or “poor.” For all studies, we evaluated applicability to populations likely to be encountered in primary care screening settings. Discrepancies in quality ratings were resolved by discussion and consensus.

The quality of each study was assessed using criteria established by the USPSTF, and except for subclinical hyperthyroidism where no good or fair quality studies were found, poor quality studies were excluded from review.

## Data Synthesis

We assessed overall strength for each body of evidence addressing a particular key question or part of a key question (for example, different treatments or screening tests) using guidance from the Strength of Evidence chapter of the AHRQ EHC Program Methods Guide for Effectiveness and Comparative Effectiveness Reviews available at:http://effectivehealthcare.ahrq.gov/ehc/products/60/294/2009_0805_grading.pdf.

To assign an overall strength of evidence (“high,” “moderate,” “low,” or “insufficient”) we considered the number, quality, and size of studies; consistency of results between studies; and directness of evidence.

## External Review

We distributed a draft of the report for review by external experts not affiliated with AHRQ or the USPSTF, and have revised the report based on their comments as well as on comments received during the public review period.