# Discussion

Tables 21 and 22 summarize our findings by key question.

Table 21 Summary of evidence for subclinical hypothyroidism

Key Question | Study Type: Number of studies Number of subjects | Risk of Bias | Consistency | Directness | Precision | Comments | Magnitude of effect (strength of evidence)
KQ 1. Does screening for subclinical thyroid dysfunction reduce morbidity or mortality? | No studies | NA | NA | NA | NA | | No evidence (Insufficient)
KQ 2. What are the harms of screening for subclinical thyroid dysfunction? | 2 studies | NA | No major inconsistency | Indirect; Low to moderate applicability to primary care | NA | No RCTs were identified; two natural history studies demonstrating indirect evidence of potential harm were included | (Insufficient)
KQ 3. Does treatment of patients with subclinical hypothyroidism detected by screening affect outcomes?
Cardiovascular events, coronary artery disease, and heart failure | No studies | NA | NA | NA | NA | | No evidence (Insufficient)
Overall quality of life | RCT: 2 169 | Medium | Consistent | Indirect; Moderate applicability to primary care setting | Imprecise: Small studies of 100 and 69 subjects | | No effect (Low)
Changes in mood/cognition | RCT: 2 169 | Medium | Consistent | Indirect; Moderate applicability to primary care setting | Imprecise: Small studies of 100 and 69 subjects | | No effect (Low)
Weight/BMI changes | RCT: 4 305 | Medium | Consistent | Indirect | Imprecise; The largest study had 100 subjects; the smallest had 23 | | No effect (Low)
Blood pressure changes | RCT: 2 195 | Medium | Consistent | Indirect; Low applicability to asymptomatic patients in primary care settings | Imprecise | | No effect (Low)
Changes in lipid levels | RCT: 4 379 | Medium | Inconsistent | Indirect; Low applicability to asymptomatic patients in U.S. primary care settings | Imprecise | | Small effect for LDL and total cholesterol (Low)
KQ 4. What are the harms of treatment of subclinical hypothyroidism and subclinical hyperthyroidism? | No Studies | NA | NA | NA | NA | | (Insufficient)

Abbreviations: BMI=body mass index; LDL=low-density lipoprotein; NA=not applicable; RCT=randomized controlled trial.

Table 22 Summary of evidence for subclinical hyperthyroidism

Key Question | Study Type: Number of studies Number of subjects | Risk of Bias | Consistency | Directness | Precision | Comments | Magnitude of effect strength of evidence
KQ 1. Does screening for subclinical thyroid dysfunction reduce morbidity or mortality? | No studies | NA | NA | NA | NA | | No evidence (Insufficient)
KQ 2. What are the harms of screening for subclinical thyroid dysfunction? | No studies | NA | NA | NA | NA | NA | No evidence (Insufficient)
KQ 3. Does treatment of patients with subclinical hyperthyroidism detected by screening affect outcomes?
Cardiovascular events including angina, atrial fibrillation, and other clinically significant arrhythmias | No studies | NA | NA | NA | NA | | No evidence (Insufficient)
Fractures | No studies | NA | NA | NA | NA | | No evidence (Insufficient)
Overall quality of life | No studies | NA | NA | NA | NA | | No evidence (Insufficient)
Changes in mood/cognition | No studies | NA | NA | NA | NA | | No evidence (Insufficient)
Weight/BMI changes | Controlled trial: 1 14 | High | NA | Direct . | Imprecise | | About 1% greater decrease in BMI in treated as compared to placebo group; absolute change in BMI in treated group of 0.5 kg/m^2^ (Insufficient)
Blood pressure changes | RCT: 1 20 Controlled trial: 1 14 | High | Inconsistent | Indirect; Treated subjects in one study included 2 patients with Graves disease and 8 with autonomous nodules | Imprecise | | 2.58 mmHG reduction daytime systolic blood pressure from 1 study; no change in 2^nd^ study (Insufficient)
Changes in bone density (as measured by DEXA scan) | RCT: 1 20 | High | NA | Indirect; Treated subjects included 2 patients with Graves disease and 8 with autonomous nodules | Imprecise | | No effect (Insufficient)
Changes in lipid levels | RCT: 1 20 | High | NA | Indirect; Treated subjects included 2 patients with Graves disease and 8 with autonomous nodules | Imprecise | | No effect (Insufficient)
KQ4. What are the harms of treatment of subclinical hyperthyroidism and subclinical hyperthyroidism? | No studies | NA | NA | NA | NA | | Insufficient

Abbreviations: BMI=body mass index; DEXA=dual-energy X-ray absorptiometry; NA=not applicable; RCT=randomized controlled trial

## Benefits of Screening/Treatment

No comparative studies have evaluated the benefits of screening for thyroid disease versus no screening (Key Question 1). Thus, it remains unknown if screening the general population with a serum TSH test will improve outcomes. The rationale for screening is based on the premise that subclinical hypothyroidism and hyperthyroidism have an inherent detrimental effect on health. We did not systematically review the literature concerning the relationship between mildly elevated TSH levels and long-term cardiovascular and cognitive effects. In previous systematic reviews, the relationship between subclinical hypothyroidism and risk factors for coronary disease was inconsistent. More recent studies, in particular the reanalysis of the Whickham data, suggest that subclinical hypothyroidism may be associated with increased cardiovascular morbidity over 20 years, but the validity and practical value of this observation is unclear. For example, whether a mildly elevated TSH confers additional risk for coronary events in the current era of widespread screening and treatment of hyperlipidemia is unclear, and the new data do not permit any estimate of the additional predictive ability of a TSH level above that of widely used risk assessment instruments based on the Framingham study.

Additionally, it is still unknown if treating individuals found to have subclinical thyroid dysfunction through population-based screening is beneficial compared with watchful waiting. In attempting to demonstrate the benefit of treatment, the literature contained a fair number of rigorous studies that looked at a variety of physiological parameters. These studies represent potentially important work that might someday help explain all the effects of thyroid hormone within the body and help explain why thyroid hormone is beneficial. However, we found only six trials of good or fair quality that reported outcomes that were in our analytic framework. No studies assessed effects on cardiac events. None of the studies found an improvement in patient-centered outcomes. Within the included studies, BMI/weight and measures of well-being were the only patient-centered outcomes evaluated, and improvement with treatment was not found. Four studies evaluated changes in intermediate outcomes that were included in our analytic framework. The findings regarding lipids were inconsistent, with two of the four studies finding some improvement and two finding no change.81,84-86 Neither of the two studies evaluating blood pressure found a significant change.84,86

The literature surrounding subclinical hyperthyroidism was particularly sparse; we only found two poor quality controlled trials. One found a slight improvement in weight gain after 12 months of treatment with methimazole, but no change in blood pressure. The other study found a small decrease in the mean daytime systolic blood pressure.77,83

## Harms of Screening/Treatment (Key Questions 2 and 4)

The harms of screening are still poorly studied. Indirect evidence appears to indicate that overdiagnosis, and thus, over-treatment could be a potential problem.

The harms of treatment also remain insufficiently studied. We found no studies that primarily focused on the harms of treatment. Of the studies that evaluated the benefits of treating subclinical hypothyroidism, only one reported that no subjects had side effects that required withdrawal or dose reduction.86 One study that evaluated the benefits of subclinical hyperthyroidism, reported simply that there was no “increase in confusion, myopathy, atrial fibrillation, and deep tendon reflexes” with treatment.77

## Strength of Evidence

The EPC strength of evidence assessment involves assessing the body of literature based on four domains: risk of bias, consistency, directness, and precision.

### Risk of Bias

The possibility of bias or error within the studies that evaluated the benefits of treating subclinical hypothyroidism was moderate. Of the six trials that evaluated the benefits of treating subclinical hypothyroidism, one study was judged to be of good quality,84 the other five, fair quality. The fair-quality studies did not adequately describe their randomization, allocation, and/or blinding.80-82, 85, 86

The possibility of bias within the studies that evaluated the benefits of treating subclinical hyperthyroidism was high. Both of these studies were of poor quality; assigning treatment or placebo via alternate assignment and offering the patients the options of switching arms once assigne83 , and not describing randomization, allocation concealment, or blinding.77 Additionally, in one study different treatments were used in the treatment arm.77

### Consistency

The four trials that evaluated the effect of thyroid replacement therapy on lipids in subjects with subclinical hypothyroidism were inconsistent. Two trials demonstrated improvement in lipids84,85 while another two trials showed no improvement.81,86 Blood pressure changes with thyroid replacement were also evaluated, and two studies were consistent in demonstrating no improvement.84,86

Of the two patient-centered outcomes evaluated in trials evaluating the benefits of treatment, four studies were consistent in showing no benefit of weight/BMI change,80,81,84,86 and two studies were consistent in failing to show improvement in measures of well-being.82,84

Of the two studies evaluating the benefits of treating subclinical hyperthyroidism, both looked at blood pressure. One study found improvement in the mean, daytime systolic blood pressure77 while the other did not.83

### Directness

For the purposes of this report, directness refers to both the applicability of a study to the population specified for this review (i.e., asymptomatic, non-pregnant individuals seen in primary care settings) and to the degree to which one can directly associate the intervention to a patient-centered outcome. As defined by our analytic framework, these include: coronary artery disease, congestive heart failure, measures of well-being, weight change, progression to overt disease, osteoporotic fractures, and atrial fibrillation. None of the trials included in this review found improvement in these outcomes.

The only benefit found was for lipids, an intermediate outcome for which results were inconsistent.

### Applicability

Because (1) the topic was nominated with regard to a particular practice setting (primary care); (2) the key questions address a specific population (asymptomatic, non-pregnant individuals); and (3) this review will be used by a body, the USPSTF, to make a recommendation regarding screening for subclinical thyroid dysfunction, this review considered directness to include the domain of applicability. Several aspects of these trials make their applicability to the general U.S. population a concern. First, none of the studies occurred in the U.S. Most of the studies recruited subjects from specialty clinics, rather than from the primary care setting. Additionally, the studies were relatively short, the longest lasting 12 months. The applicability of studies of this duration to a condition that is generally life-long was unclear.

### Precision

The studies included in the review were small. Among studies of subclinical hypothyroidism, the largest contained 120 individuals,85 with the smallest having only 23 subjects.80 Of the two studies of subclinical hyperthyroidism, one had 20 subjects77 and one 14.^83^ Due to the small sample size, none of the included studies were judged to provide a precise estimation of the effect of treatment.

## Limitations

This review was designed to address a very narrow clinical question that lies in the uncertainty of modern clinical practice: What are the benefits and harms of screening and subsequently treating subclinical thyroid dysfunction. Not only is this a critical question to answer for patient management, but also to determine if screening for subclinical thyroid dysfunction is warranted. In particular, not only would screening find individuals with subclinical thyroid dysfunction, but it would also identify individuals with overt thyroid disease. While it remains unclear just how many individuals will have undetected overt thyroid dysfunction in primary care practices, a large population-based prevalence study performed in Colorado estimates that about 0.5 percent of the population might have unrecognized overt thyroid dysfunction.7 While it was unclear how many of these individuals might benefit from screening in primary care practices, it is likely that some would; thus, the benefit of screening may be underestimated by this review. Moreover, unlike the previous AHRQ report, we did not systematically review studies of the natural history of subclinical hypothyroidism or reevaluate literature on this subject that was included in previous reviews.

Additionally, this review compared the benefits and harms of screening with not screening for subclinical thyroid dysfunction in primary care practices. The benefits and harms of a third approach, case-finding, was not evaluated. As described earlier in this review, case-finding is different from screening in that after a TSH is obtained on all individuals, those with a high TSH are brought back for a detailed thyroid focused history. The decision to treat is then based on both the lab value and on the history obtained. This approach may allow those who will most benefit from treatment to be identified in the most efficient manner. By not including case-finding as a diagnostic strategy, it is possible that this review failed to evaluate a valid method of determining thyroid dysfunction in primary care practices.

Most of the studies included in this review did not recruit patients from primary care practices. Additionally, one of the systematic reviews included contained three studies that had individuals with known thyroid dysfunction. Ideally, we would have included only studies that included screen-detected thyroid dysfunction from primary care practices; however, the paucity of studies compelled the use of less than ideal studies. This limits the applicability to primary care practices and to screened populations.

Finally, the individual studies that were included in this review used different lab values as the cutoff for an abnormal TSH and for normal FT4 and used different doses of levothyroxine, making comparisons between studies difficult. Because of this clinical heterogeneity, a meta-analysis was not conducted.

## Summary of Review Findings

As in 2004, there remains insufficient evidence directly linking screening of asymptomatic individuals for subclinical thyroid dysfunction to improvements in morbidity or mortality. However, a growing body of evidence, which this review rates as low quality, continues to suggest that treating subclinical hypothyroidism is not any more beneficial than watchful waiting for overall quality of life, mood or cognition, weight/BMI, or blood pressure changes. Studies regarding lipids remain inconsistent, small, and of varying quality. We, therefore, regard the evidence concerning lipids as insufficient to determine if treatment is more beneficial than watchful waiting. Larger trials of treatment that are longer in duration would be helpful in improving the quality of evidence for all of these outcomes.

The following information from this report may be helpful to the practicing clinician:

- It is still unclear if subclinical thyroid dysfunction has any impact on patient outcomes; systematic reviews included in this report regarding all-cause mortality and coronary artery disease mortality were inconsistent, and indicated that even if treatment is effective, a clinician would need to screen and treat a large number of patients before seeing a benefit to any individual patient
- We know that in some natural history studies, as many as 37 percent of patients initially found to have a elevated TSH and normal free T4 may have a normal TSH within the three years following initial testing
- We know, therefore, that there is potential for serious harms, including atrial fibrillation and angina, from unnecessary treatment or overtreatment of subclinical thyroid dysfunction, although in most cases reported harms appear to be minor, such as increased anxiety and nervousness, and are likely to improve with discontinuation of therapy
- The strength of evidence is low that treating subclinical hypothyroidism will lead to improvement in quality of life, mood, cognition, weight/BMI, or blood pressure when compared with watchful waiting
- Finally, we know that the current evidence is inconsistent, with a low overall strength of evidence with regards to the benefits of treatment of subclinical hypothyroidism for lipids, that improvement is likely to be modest at best, and is likely to be of little clinical significance.

As in all cases, this evidence should be considered, along with the clinician’s knowledge of the individual, in making clinical judgments about the appropriate care for each patient. For instance, one might consider levothyroxine therapy in an individual with both subclinical hypothyroidism and dyslipidemia who also reports several symptoms of thyroid dysfunction, but who is at low risk for atrial fibrillation and other possible side effects. However, an individual at higher risk of atrial fibrillation, who has no or few hypothyroid symptoms, or who is known to be prone to anxiety might not be a good candidate for treatment.

## Emerging Issues/Next Steps

Currently, progression to overt disease is the best established complication of subclinical thyroid dysfunction. Other possible complications of subclinical hypothyroidism still need to be fully delineated. The Whickham study was recently re-analyzed and found that the original study might have underestimated the association between subclinical hypothyroidism and risk for coronary events over 20 years.47 Other analyses suggest that subclinical hypothyroidism may be associated with cardiovascular disease in subjects younger than 65 years, but that the magnitude of risk is low.45 These analyses, however, do not establish the prognostic value of a TSH when added to existing risk scoring systems for cardiovascular events, particularly in the age of aggressive lipid therapy. Continuing work in this area should improve our understanding of the risks of cardiovascular complications in people with subclinical thyroid dysfunction and how those risks vary among different subpopulations.

Additionally, reversion of mildly elevated TSH levels may be more common than previously thought. Recent studies suggest that reversion can occur even after a long period of persistent elevation. A recent longitudinal study found that of 102 women with TSH between 0.1 and 0.4 mIU/L 3 percent progressed to overt hyperthyroidism while 24 percent reverted to normal.52 In a cross-sectional study of individuals in their 80s, after three years, of 12 subjects initially found to have subclinical hyperthyroidism, only one had progressed to overt disease and five had reverted to normal TSH levels.87 In that same study, in 21 out of 30 individuals reassessed after initially found to have subclinical hypothyroidism, none had progressed to overt disease, and 11 had reverted to normal TSH levels. Studies to discover who might progress to overt disease versus who might revert back to a normal TSH and the time frame for which this might occur would be helpful in determining who should be considered for early treatment and for whom watchful waiting might be more appropriate.

Finally, three recent studies suggest that in the elderly population a slightly elevated TSH might have a protective effect, questioning the conventional wisdom surrounding treating subclinical hypothyroidism.87,90,91 Taken together, these findings suggest the need for a better understanding of the impact on health outcomes of mildly elevated and mildly depressed TSH levels and how those impacts vary for different subpopulations, particularly the elderly.

## Future Research

Because the prevalence of subclinical thyroid dysfunction in the general population may be as high as 7 percent in women and 5 percent in men,1 determining the harms and benefits of screening and treating thyroid disease has the potential to significantly affect the health of many. Many experts who favor early treatment acknowledge the need for appropriately powered RCTs comparing early treatment with thyroxine therapy to active surveillance or expectant management in patients who have a mildly increased serum TSH level.

Prior to conducting trials of screening for subclinical thyroid dysfunction, it may be important to conduct well-designed trials of treatment versus delayed treatment. Any condition that is considered appropriate for screening must have an intervention that can clearly improve a clinical outcome. It would be ideal if the benefits of treatment and an understanding of which individuals may benefit from treatment were understood prior to determining if screening the general population is warranted. For a condition to be considered appropriate for screening, there must be an intervention that can improve a clinical outcome. To date, it remains unclear if treating subclinical thyroid dysfunction leads to improvement in patient-centered outcomes. Furthermore, subclinical thyroid dysfunction may only pose a health risk to a particular subpopulation, and if there is a health risk, treatment may only be effective beyond a specific TSH threshold. Well designed trials of early versus delayed treatment should be conducted to determine this. If a treatment benefit is found, then well designed screening trials should be conducted to determine if screening in the general population is beneficial.

Any trial designed to answer the key questions in this review should follow subjects for at least three years, preferably longer, and should be powered to detect the harms of therapy. Such a trial should recruit subjects who were identified by screening and preferably from primary care practices. Outcomes of interest should include patient-centered outcomes, similar to the ones outlined in our analytic framework, and any tool used to assess quality of life should be well-recognized and have a proven track-record. The validity of such a trial can be increased by requiring a longer pre-randomization period to ensure that subjects have persistently high TSH levels, and by including and stratifying subjects who have serologic evidence of autoimmunity.