# Results of Search for Systematic Reviews

Thyroid disease in pregnancy. ACOG Technical Bulletin Number 181—June 1993. Int J Gynaecol Obstet. 1993/10/01. ed1993:82-8.
Abraham P, Avenell A, Watson WA, Park CM, Bevan JS. Antithyroid drug regimen for treating Graves' hyperthyroidism. Cochrane Database of Systematic Reviews. 2009.
Ahangari Z, Nasser M, Mahdian M, Marchesan MA, Fedorowicz Z. Interventions for the management of external root resorption. Cochrane Database of Systematic Reviews. 2009.
Angermayr L, Clar C. Iodine supplementation for preventing iodine deficiency disorders in children. Cochrane Database of Systematic Reviews. 2009.
Ardaillou R, Le Gall JY. Commission IdlANdM. [Mass neonatal screening using biological testing]. Gynecol Obstet Fertil. 2007/04/03. ed2007:367-74.
Balaguer A, Escribano J, Feliu A, Roque i, Figuls M. Dietary interventions for preventing complications in idiopathic hypercalciuria. Cochrane Database of Systematic Reviews. 2009.
Balogh R, Ouellette-Kuntz H, Bourne L, Lunsky Y, Colantonio A. Organising health care services for persons with an intellectual disability. Cochrane Database of Systematic Reviews. 2009.
Barrington KJ, Brion LP. Dopamine versus no treatment to prevent renal dysfunction in indomethacin-treated preterm newborn infants. Cochrane Database of Systematic Reviews. 2009.
Baskin HJ, Cobin RH, Duick DS, Gharib H, Guttler RB, Kaplan MM, et al. American Association of Clinical Endocrinologists medical guidelines for clinical practice for the evaluation and treatment of hyperthyroidism and hypothyroidism. Endocr Pract. 2004/07/21. ed2002:457-69.
Biondi B, Palmieri EA, Lombardi G, Fazio S. Effects of subclinical thyroid dysfunction on the heart. Ann Intern Med. 2002/12/03. ed2002:904-14.
Bjorndal MM, Sandmo Wilhelmsen K, Lu T, Jorde R. Prevalence and causes of undiagnosed hyperthyroidismin an adult healthy population. The Tromso study. J Endocrinol Invest. 2008/12/19. ed2008:856-60.
Bjornstad GJ, Montgomery P. Family therapy for attention-deficit disorder or attention-deficit/hyperactivity disorder in children and adolescents. Cochrane Database of Systematic Reviews. 2009.
Burgess A, Kundu S. Diuretics for Meniere's disease or syndrome. Cochrane Database of Systematic Reviews. 2009.
Committee on Patient S, Quality I, Committee on Professional L. ACOG Committee Opinion No 381: Subclinical hypothyroidism in pregnancy. Obstet Gynecol. 2007/10/02. ed2007:959-60.
Cramp F, Daniel J. Exercise for the management of cancer-related fatigue in adults. Cochrane Database of Systematic Reviews. 2009.
Danese MD, Ladenson PW, Meinert CL, Powe NR. Clinical review 115: effect of thyroxine therapy on serum lipoproteins in patients with mild thyroid failure: a quantitative review of the literature. J Clin Endocrinol Metab. 2000/09/22. ed2000:2993-3001.
Das A, Shah PS. Octreotide for the treatment of chylothorax in neonates. Cochrane Database of Systematic Reviews. 2009.
de Vries L, Bulvik S, Phillip M. Chronic autoimmune thyroiditis in children and adolescents: at presentation and during long-term follow-up. Arch Dis Child. 2008/08/16. ed2009:33-7.
Debieve F, Duliere S, Bernard P, Hubinont C, De Nayer P, Daumerie C. To treat or not to treat euthyroid autoimmune disorder during pregnancy?. Gynecol Obstet Invest. 2008/12/19. ed2009:178-82.
Dissemination CfRa. Effects on bone mass of long term treatment with thyroid hormones: a meta-analysis (Structured abstract). Database of Abstracts of Reviews of Effects. 2010.
Dissemination CfRa. The efficacy of thyroidectomy for Graves' disease: a meta-analysis (Structured abstract). Database of Abstracts of Reviews of Effects. 2010.
Dissemination CfRa. Radioiodine therapy (RAI) for Graves' disease (GD) and the effect on ophthalmopathy: a systematic review (Structured abstract). Database of Abstracts of Reviews of Effects. 2010.
Duley L, Gulmezoglu AM, Henderson-Smart DJ. Magnesium sulphate and other anticonvulsants for women with pre-eclampsia. Cochrane Database of Systematic Reviews. 2009.
Eftimov F, Winer JB, Vermeulen M, de Haan R, van Schaik IN. Intravenous immunoglobulin for chronic inflammatory demyelinating polyradiculoneuropathy. Cochrane Database of Systematic Reviews. 2009.
Escribano J, Balaguer A, Pagone F, Feliu A, Roque i, Figuls M. Pharmacological interventions for preventing complications in idiopathic hypercalciuria. Cochrane Database of Systematic Reviews. 2009.
Faber J, Galloe AM. Changes in bone mass during prolonged subclinical hyperthyroidism due to L-thyroxine treatment: a meta-analysis. Eur J Endocrinol. 1994/04/01. ed1994:350-6.
Franchini M, Lippi G, Targher G. Hyperthyroidism and Venous Thrombosis: A Casual or Causal Association? A Systematic Literature Review. Clin Appl Thromb Hemost. 2010/Mar/22.
Galofre Ferrater, JC Corrales, Hernandez JJ, Perez Corral B, Canton Blanco A, Alonso Pedrol N, Perez Perez A, et al. [Clinical guideline for the diagnosis and treatment of subclinical thyroid dysfunction in pregnancy Working Group on Subclinical Thyroid Dysfunction of the Spanish Endocrinology Society]. Endocrinol Nutr. 2009/07/25. ed2009:85-91.
Goedendorp MM, Gielissen MFM, Verhagen CA, Bleijenberg G. Psychosocial interventions for reducing fatigue during cancer treatment in adults. Cochrane Database of Systematic Reviews. 2009.
Gorman CA, Garrity JA, Fatourechi V, Bahn RS, Petersen IA, Stafford SL, et al. The aftermath of orbital radiotherapy for graves' ophthalmopathy. Ophthalmology. 2002/11/05. ed2002:2100-7.
Heemstra KA, Hamdy NA, Romijn JA, Smit JW. The effects of thyrotropin-suppressive therapy on bone metabolism in patients with well-differentiated thyroid carcinoma. Thyroid. 2006/07/15. ed2006:583-91.
Helfand M. Screening for Thyroid Disease. Rockville, MD. U.S. Department of Health and Human Services, Agency for Healthcare Research and Quality. 2004.
Helfand M, Force USPST. Screening for subclinical thyroid dysfunction in nonpregnant adults: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2004/01/22. ed2004:128-41.
Helfand M, Redfern CC. Clinical guideline, part 2 Screening for thyroid disease: an update. American College of Physicians. Ann Intern Med. 1998/07/21. ed1998:144-58.
Ibrahim MDH, Sinn JKH, McGuire W. Iodine supplementation for the prevention of mortality and adverse neurodevelopmental outcomes in preterm infants. Cochrane Database of Systematic Reviews. 2009.
Iglesias P, Devora O, Garcia J, Tajada P, Garcia-Arevalo C, Diez JJ. Severe hyperthyroidism: aetiology, clinical features and treatment outcome. Clin Endocrinol (Oxf). 2009/Aug/4.
Kaptein EM, Beale E, Chan LS. Thyroid hormone therapy for obesity and nonthyroidal illnesses: a systematic review. J Clin Endocrinol Metab. Oct. 2009;94(10):3663-75. [pmid: 19737920].
Krassas GE. Thyroid disease and female reproduction. Fertil Steril. 2000/12/20. ed2000:1063-70.
Lees C, Davies SC, Dezateux C. Neonatal screening for sickle cell disease. Cochrane Database of Systematic Reviews. 2009.
Leffers N, Daemen T, Helfrich W, Boezen HM, Cohlen BJ, Melief K, et al. Antigen-specific active immunotherapy for ovarian cancer. Cochrane Database of Systematic Reviews. 2009(1).
Leite FMG, Atallah AN, El Dib RP, Grossmann E, Januzzi E, Andriolo RB, et al. Cyclobenzaprine for the treatment of myofascial pain in adults. Cochrane Database of Systematic Reviews. 2009.
Lindstedt G, Eliasson M. [Insufficient evidence for the need of screening and treatment of subclinical thyroid function disorders. Evidence-based analysis]. Lakartidningen. 2005/02/15. ed2005:30-2. 5.
Ma C, Kuang A, Xie J. Radioiodine therapy for differentiated thyroid carcinoma with thyroglobulin positive and radioactive iodine negative metastases. Cochrane Database of Systematic Reviews. 2009.
Ma C, Kuang A, Xie J, Liu GJ. Radioiodine treatment for pediatric Graves' disease. Cochrane Database of Systematic Reviews. 2009.
Ma C, Xie J, Liu W, Wang G, Zuo S, Wang X, et al. Recombinant human thyrotropin (rhTSH) aided radioiodine treatment for residual or metastatic differentiated thyroid cancer. Cochrane Database of Systematic Reviews. 2009(1).
Manfredi E, van Zaane B, Gerdes VE, Brandjes DP, Squizzato A. Hypothyroidism and acquired von Willebrand's syndrome: a systematic review. Haemophilia. 2008/01/26. ed2008:423-33.
Mock V, Atkinson A, Barsevick A, Cella D, Cimprich B, Cleeland C, et al. NCCN Practice Guidelines for Cancer-Related Fatigue. Oncology (Williston Park). 2001/02/24. ed2000:151-61. x.
Ng SM, Anand D, Weindling AM. High versus low dose of initial thyroid hormone replacement for congenital hypothyroidism. Cochrane Database of Systematic Reviews. 2009.
Nygaard B. Hyperthyroidism (primary). Clin Evid (Online). 2008/01/01. ed2008.
Ochs N, Auer R, Bauer DC, Nanchen D, Gussekloo J, Cornuz J, et al. Meta-analysis: subclinical thyroid dysfunction and the risk for coronary heart disease and mortality. Ann Intern Med. 2008/05/21. ed2008:832-45.
Osborn DA. Thyroid hormones for preventing neurodevelopmental impairment in preterm infants. Cochrane Database of Systematic Reviews. 2009.
Osborn DA, Hunt R. Postnatal thyroid hormones for respiratory distress syndrome in preterm infants. Cochrane Database of Systematic Reviews. 2009.
Osborn DA, Hunt R. Prophylactic postnatal thyroid hormones for prevention of morbidity and mortality in preterm infants. Cochrane Database of Systematic Reviews. 2009.
Palmieri EA, Fazio S, Lombardi G, Biondi B. Subclinical hypothyroidism and cardiovascular risk: a reason to treat?. Treat Endocrinol. 2005/07/20. ed2004:233-44.
Peng J, Gu M-J. [Influence of thyroxine treatment on serum lipid levels in patients with subclinical hypothyroidism: A meta-analysis]. Academic Journal of Second Military Medical University. 2007:519-23.
Peters-Veluthamaningal C, van der Windt DAWM, Winters JC, Meyboom-de Jong B. Corticosteroid injection for trigger finger in adults. Cochrane Database of Systematic Reviews. 2009.
Pham CB, Shaughnessy AF. Should we treat subclinical hypothyroidism?. BMJ. 2008/07/18. ed.2008:a834.
Ponto KA, Pitz S, Mann WJ, Weber MM, Pfeiffer N, Kahaly GJ. [Management of Graves' orbitopathy: evidence-based recommendations]. Dtsch Med Wochenschr. Dec. 2009;134(49):2521-4. [pmid: 19941237].
Poppe K, Glinoer D. Thyroid autoimmunity and hypothyroidism before and during pregnancy. Hum Reprod Update. 2003/05/20. ed2003:149-61.
Porterfield JR Jr, Thompson GB, Farley DR, Grant CS, Richards ML. Evidence-based management of toxic multinodular goiter (Plummer's Disease). World J Surg. 2008/03/22. ed2008:1278-84.
Quan ML, Pasieka JL, Rorstad O. Bone mineral density in well-differentiated thyroid cancer patients treated with suppressive thyroxine: a systematic overview of the literature. J Surg Oncol. 2002/01/05. ed2002:62-9. discussion 9-70.
Rambaldi A, Gluud C. Propylthiouracil for alcoholic liver disease. Cochrane Database of Systematic Reviews. 2009.
Reid SM, Middleton P, Crowther CA, Cossich MC. Interventions for clinical and subclinical hypothyroidism in pregnancy. Cochrane Database of Systematic Reviews. 2009.
Schiff GD, Kim S, Krosnjar N, Wisniewski MF, Bult J, Fogelfeld L, et al. Missed hypothyroidism diagnosis uncovered by linking laboratory and pharmacy data. Arch Intern Med. 2005/03/16. ed2005:574-7.
Shah VS, Ohlsson A. Venepuncture versus heel lance for blood sampling in term neonates. Cochrane Database of Systematic Reviews. 2009.
Simescu M, Dumitrescu C, Balmes E, Ursu H, Vaida E, Varciu M, et al. A retrospective study on the treatment and evolution of Graves' ophthalmopathy. Rom J Endocrinol. 1992/01/01. ed1992:149-58.
Singhal T, Bansal S, Singhal A, McDonald S, Bal CS. Adjunctive antithyroid drugs in radioiodine therapy for hyperthyroidism. Cochrane Database of Systematic Reviews. 2009.
Stiebel-Kalish H, Robenshtok E, Hasanreisoglu M, Ezrachi D, Shimon I, Leibovici L. Treatment modalities for Graves' ophthalmopathy: systematic review and metaanalysis. J Clin Endocrinol Metab. Aug. 2009;94(8):2708-16. [pmid: 19491222].
Sundaram S, Lim J, Lasserson TJ. Surgery for obstructive sleep apnoea in adults. Cochrane Database of Systematic Reviews. 2009.
Surks MI, Boucai L. Age-and race-based serum thyrotropin reference limits. J Clin Endocrinol Metab. 2009/12/08. ed2010:496-502.
Surks MI, Ortiz E, Daniels GH, Sawin CT, Col NF, Cobin RH, et al. Subclinical thyroid disease: scientific review and guidelines for diagnosis and management. JAMA. 2004/01/15. ed2004:228-38.
Tan A, Xia N, Gao F, Mo Z, Cao Y. Angiogenesis-inhibitors for metastatic thyroid cancer. Cochrane Database of Systematic Reviews. 2010(3).
Tanis BC, Westendorp GJ, Smelt HM. Effect of thyroid substitution on hypercholesterolaemia in patients with subclinical hypothyroidism: a reanalysis of intervention studies. Clin Endocrinol (Oxf). 1996/06/01. ed1996:643-9.
Uzzan B, Campos J, Cucherat M, Nony P, Boissel J, Perret G. Effects on bone mass of long term treatment with thyroid hormones: a meta-analysis. J Clin Endocrinol Metab. 1996:4278-89.
Van Buggenhout GJ, Trommelen JC, Schoenmaker A, De Bal C, Verbeek JJ, Smeets DF, et al. Down syndrome in a population of elderly mentally retarded patients: genetic-diagnostic survey and implications for medical care. Am J Med Genet. 1999/07/09. ed1999:376-84.
van Trotsenburg AS, Vulsma T, van Rozenburg-Marres SL, van Baar AL, Ridder JC, Heymans HS, et al. The effect of thyroxine treatment started in the neonatal period on development and growth of two-year-old Down syndrome children: a randomized clinical trial. J Clin Endocrinol Metab. 2005/03/10. ed2005:3304-11.
Villar HC, Saconato H, Valente O, Atallah AN. Thyroid hormone replacement for subclinical hypothyroidism. Cochrane Database Syst Rev. 2007/07/20. ed2007:CD003419.
Volzke H, Schwahn C, Wallaschofski H, Dorr M. Review: The association of thyroid dysfunction with all-cause and circulatory mortality: is there a causal relationship?. J Clin Endocrinol Metab. 2007/05/03. ed2007:2421-9.
Weetman AP. Radioiodine treatment for benign thyroid diseases. Clin Endocrinol (Oxf). 2007/05/01. ed2007:757-64.
Wiersinga WM. [The practice guideline 'Thyroid disorders' (first revision) from the Dutch College of General Practitioners; a response from the perspective of internal medicine]. Ned Tijdschr Geneeskd. 2008/02/02. ed2007:2822-4.
Wilcken B. Evaluating outcomes of newborn screening programs. Southeast Asian J Trop Med Public Health. 2005/05/24. ed2003:13-8.
Woodward S, Norton CS, Gordon J. Reflexology for treatment of constipation. Cochrane Database of Systematic Reviews. 2009(1).
Wu T, Liu GJ, Li P, Clar C. Iodised salt for preventing iodine deficiency disorders. Cochrane Database of Systematic Reviews. 2009.
Xander C, Meerpohl JJ, Galandi D, Buroh S, Motschall E, Schwarzer G, et al. Pharmacological interventions for pruritus in adult palliative care patients. Cochrane Database of Systematic Reviews. 2009(1).
Xue S, Gu R, Wu T, Zhang M, Wang X. Oral potassium iodide for the treatment of sporotrichosis. Cochrane Database of Systematic Reviews. 2010(2).
Zeng X, Yuan Y, Wu T, Yan L, Su H. Chinese herbal medicines for hyperthyroidism. Cochrane Database of Systematic Reviews. 2009.