# Screening and Case-Finding Recommendations of Other Groups

Organization | Guideline
ATA 2000 [Ladenson 2000] | Adults should be screened for thyroid dysfunction by measurement of the serum thyrotropin concentration, beginning at age 35 years and every 5 years thereafter.
IOM, 2003^12^ | There is insufficient evidence to recommend periodic, routine screening for thyroid dysfunction among asymptomatic persons using serum TSH levels.
USPSTF 2004 [Ann Intern Med. 2004;140:125-127] | Evidence is insufficient to recommend for or against routine screening for thyroid disease in adults
AACE, ATA, Endocrine Society, 2004 [Surks 2004] | The panel recommends against population-based screening for thyroid disease. Case ascertainment in certain high risk groups is encouraged. The panel finds the evidence insufficient to recommend for or against routine determination of TSH levels (screening) in pregnant women or women planning to become pregnant. It is reasonable to consider serum TSH measurement for women with a family history of thyroid disease, prior thyroid dysfunction symptoms or physical findings suggestive of hypothyroidism or hyperthyroidism, an abnormal thyroid gland on examination, type 1 diabetes mellitus, or a personal history of an autoimmune disorder.
AACE, ATA, Endocrine Society, 2004 [Gharib 2005] | Consensus statement favors routine screening for subclinical thyroid dysfunction in adults, including pregnant women and those contemplating pregnancy
British Thyroid Association 2006 | - If screening is performed, and a high serum TSH concentration and normal FT4 is found, repeat measurement 3-6 months later after excluding non-thyroidal illness and drug interference.; - If the TSH is mildly elevated (above the reference range but below 10 mU/L), obtain serum thyroid peroxidase antibodies.If antibody levels are high, repeat measurement of TSH annually.; - If they are low, repeat measurement of TSH every 3 years. Initiate treatment if the TSH level is greater than 10 mU/L or the patient develops clinical findings of hypothyroidism.
ACOG, 2007[ ACOG Committee Opinion No. 381: Subclinical Hypothyroidism in Pregnancy] | Based on current literature, thyroid testing in pregnancy should be performed on symptomatic women and those with a personal history of thyroid disease or other medical conditions associated with thyroid disease (eg, diabetes mellitus). Without evidence that identification and treatment of pregnant women with subclinical hypothyroidism improves maternal or infant outcomes, routine screening for subclinical hypothyroidism currently is not recommended.
AAFP [AAFP web site accessed 1/4/2010] | The AAFP concludes that the evidence is insufficient to recommend for or against routine screening for thyroid disease in adults.
ACP [web site accessed 1/4/2010] | No current guidelines. Recommends reviewing guidelines of USPSTF.

Abbreviations: AACE=American Association of Clinical Endocrinologists; AAFP=American Academy of Family Physicians; ACOG=American Congress of Obstetricians and Gynecologists; ACP=American College of Physicians; ATA=American Thyroid Association; IOM=Institute of Medicine; USPSTF=United States Preventive Services Task Force.