# Excluded Studies

## Excluded Systematic Reviews

Baskin HJ, Cobin RH, Duick DS, Gharib H, Guttler RB, Kaplan MM, et al. American Association of Clinical Endocrinologists medical guidelines for clinical practice for the evaluation and treatment of hyperthyroidism and hypothyroidism. Endocr Pract. 2004/07/21. ed2002:457-69. Not a systematic review.
Biondi B, Palmieri EA, Lombardi G, Fazio S. Effects of subclinical thyroid dysfunction on the heart. Ann Intern Med. 2002/12/03. ed2002:904-14. Not a systematic review.
Bjorndal MM, Sandmo Wilhelmsen K, Lu T, Jorde R. Prevalence and causes of undiagnosed hyperthyroidismin an adult healthy population. The Tromso study. J Endocrinol Invest. 2008/12/19. ed2008:856-60. Not a systematic review.
Danese MD, Ladenson PW, Meinert CL, Powe NR. Clinical review 115: effect of thyroxine therapy on serum lipoproteins in patients with mild thyroid failure: a quantitative review of the literature. J Clin Endocrinol Metab. 2000/09/22. ed2000:2993-3001. Not in time frame for reviews.
Dissemination CfRa. Effects on bone mass of long term treatment with thyroid hormones: a meta-analysis (Structured abstract). Database of Abstracts of Reviews of Effects. 2010. Not in time frame for reviews.
Faber J, Galloe AM. Changes in bone mass during prolonged subclinical hyperthyroidism due to L-thyroxine treatment: a meta-analysis. Eur J Endocrinol. 1994/04/01. ed1994:350-6. Not in time frame for reviews.
Lindstedt G Eliasson M [Insufficient evidence for the need of screening and treatment of subclinical thyroid function disorders. Evidence-based analysis] Lakartidningen 2005/02/15 ed2005 30 2 5.Not a systematic review
Nygaard B. Hyperthyroidism (primary). Clin Evid (Online). 2008/01/01. ed2008. Not related to key questions.
Ochs N, Auer R, Bauer DC, Nanchen D, Gussekloo J, Cornuz J, et al. Meta-analysis: subclinical thyroid dysfunction and the risk for coronary heart disease and mortality. Ann Intern Med. 2008/05/21. ed2008:832-45. Not related to key questions.
Palmieri EA, Fazio S, Lombardi G, Biondi B. Subclinical hypothyroidism and cardiovascular risk: a reason to treat?. Treat Endocrinol. 2005/07/20. ed2004:233-44. Not a systematic review.
Peng L, Gu M-J. [Influence of thyroxine treatment on serum lipid levels in patients with subclinical hypothyroidism: A meta-analysis]. Academic Journal of Second Military Medical University. 2007:519-23. Poor quality systematic review.
Pham CB, Shaughnessy AF. Should we treat subclinical hypothyroidism?. BMJ. 2008/07/18. ed2008:a834. Not a systematic review.
Tanis BC, Westendorp GJ, Smelt HM. Effect of thyroid substitution on hypercholesterolaemia in patients with subclinical hypothyroidism: a reanalysis of intervention studies. Clin Endocrinol (Oxf). 1996/06/01. ed1996:643-9. Not in time frame for reviews.
Uzzan B, Campos J, Cucherat M, Nony P, Boissel J, Perret G. Effects on bone mass of long term treatment with thyroid hormones: a meta-analysis. J Clin Endocrinol Metab. 1996:4278-89. Not in time frame for reviews.
Volzke H, Schwahn C, Wallaschofski H, Dorr M. Review: The association of thyroid dysfunction with all-cause and circulatory mortality: is there a causal relationship?. J Clin Endocrinol Metab. 2007/05/03. ed2007:2421-9. Not related to key questions.

## Excluded Studies

1R01AG032317-01A1. Subclinical thyroid dysfunction in the elderly. No data (e.g. description of study only).
1R01MH080295-01A2. Subclinical Hypothyroidism: Mood, Cognition and the effect of L-thyroxine treatme. No data (e.g. description of study only).
5R01HL076645-03. Subclinical Thyroid Dysfunction & Risk of MI and Stroke. No relevance to key questions.
5R21DK062787-02. Neurocognitive effects of subclinical thyroid disease. Related to topic but does not meet criteria for study design or quality.
Abalovich M, Mitelberg L, Allami C, Gutierrez S, Alcaraz G, Otero P, et al. Subclinical hypothyroidism and thyroid autoimmunity in women with infertility. Gynecol Endocrinol. 2007/06/15. ed2007:279-83. No relevance to key questions; Wrong population.
Abbott Laboratories. No data (e.g. description of study only).
Abdelrazek SS, Rogowski F, Szumowski P, Zonenberg A, Parfie_czyk A, Szelachowska M, et al. The Outcome of Radioiodine Therapy in Patient with Subclinical Hyperthyroidism. 19th Annual Congress of the European Association of Nuclear Medicine (EANM 06). Megaron International Conference Center, Athens (Greece). 30 Sep-4 Oct 2006. 2006;(333):534. Related to topic but does not meet criteria for study design or quality.
Abdelrazek SS, Rogowski F, Zonenberg A, Szelachowska M, Nikolajuk A, Parfienczyk A, et al. The Effect of Radioiodine Therapy on Some Parameters of Oxidant/Antioxidant Balance in Patients with Subclinical Hyperthyroidism. 20th Annual Congress of the European Association of Nuclear Medicine (EANM 2007). Copenhagen Congress Center, Copenhagen (Denmark). 13-17 Oct 2007. 2007;(S353):P445. Related to topic but does not meet criteria for study design or quality.
Abdullatif HD, Ashraf AP. Reversible subclinical hypothyroidism in the presence of adrenal insufficiency. Endocr Pract. 2006/09/28. ed2006:572. Wrong population.
Adrees M, Gibney J, El-Saeity N, Boran G. Effects of 18 months of L-T4 replacement in women with subclinical hypothyroidism. Clin Endocrinol. 2009:298-303. Related to topic but does not meet criteria for study design or quality.
Akinci B, Comlekci A, Yener S, Demir T, Bayraktar F, Yuksel F, et al. The alteration of serum soluble CD40 ligand levels in overt and subclinial hypothyroidism. Hormones (Athens). 2007:327-33. Related to topic but does not meet criteria for study design or quality.
Al Sayed A, Al Ali N, Bo Abbas Y, Alfadhli E. Subclinical hypothyroidism is associated with early insulin resistance in Kuwaiti women. Endocr J. 2006/08/12. ed2006:653-7. No data (e.g. description of study only); No relevance to key questions.
Alberiche M, Boronat M, Saavedra P, Perez N, Marrero D, Lopez-Plasencia Y, et al. Thyrotropin levels and their relationship with cardiovascular risk factors in the island of Gran Canaria, Spain. Implications of lowering the upper reference limit of thyrotropin stimulating hormone. J Endocrinol Invest. 2009/05/05. ed2009:102-6. No relevance to key questions.
Algun E, Topal C, Ozturk M, Sekeroglu MR, Durmus A. Urinary beta-2 microglobulin in renal dysfunction associated with hypothyroidism. Int J Clin Pract. 2004/05/01. ed2004:240-3. Wrong population.
Alzoubi KH, Gerges NZ, Aleisa AM, Alkadhi KA. Levothyroxin restores hypothyroidism-induced impairment of hippocampus-dependent learning and memory: Behavioral, electrophysiological, and molecular studies. Hippocampus. 2008/08/06. ed2009:66-78. Wrong population.
Appetecchia M. Effects on bone mineral density by treatment of benign nodular goiter with mildly suppressive doses of L-thyroxine in a cohort women study. Horm Res. 2005/11/05. ed2005:293-8. Wrong population.
Arinzon Z, Zuta A, Peisakh A, Feldman J, Berner Y. Evaluation response and effectiveness of thyroid hormone replacement treatment on lipid profile and function in elderly patients with subclinical hypothyroidism. Arch Gerontol Geriatr. 2007:13-9. Related to topic but does not meet criteria for study design or quality.
Arrigo T, Wasniewska M, Crisafulli G, Lombardo F, Messina MF, Rulli I, et al. Subclinical hypothyroidism: The state of the art. Journal of endocrinological investigation. 2008:79-84. No data by design (e.g. opinion, letter, editorial).
Atzmon G, Barzilai N, Hollowell JG, Surks MI, Gabriely I. Extreme longevity is associated with increased serum thyrotropin. J Clin Endocrinol Metab. 2009:1251-4. Background – effect of elevated TSH.
Azizi F, Hedayati M, Rahmani M, Sheikholeslam R, Allahverdian S, Salarkia N. Reappraisal of the risk of iodine-induced hyperthyroidism: an epidemiological population survey. J Endocrinol Invest. 2005/04/09. ed2005:23-9. Wrong population.
Bakiner O, Ertorer ME, Haydardedeoglu FE, Bozkirli E, Tutuncu NB, Demirag NG. Subclinical hypothyroidism is characterized by increased QT interval dispersion among women. Med Princ Pract. 2008/08/08. ed2008:390-4. No relevance to key questions;Wrong population.
Baldini M, Colasanti A, Orsatti A, Airaghi L, Mauri MC, Cappellini MD. Neuropsychological functions and metabolic aspects in subclinical hypothyroidism: The effects of l-thyroxine. Prog Neuro Psychopharmacol Biol Psychiatry. 2009:854-9. Related to topic but does not meet criteria for study design or quality.
Bartalena L, Tanda ML, Bogazzi F, Piantanida E, Lai A, Martino E. An update on the pharmacological management of hyperthyroidism due to Graves' disease. Expert Opin Pharmacother. Juninitial search 6/11/209. 2005;6(6):851-61. Wrong population. [pmid: 15952916].
Batrinos ML. The problem of exogenous subclinical hyperthyroidism. Hormones (Athens, Greece). 2006:119-25. Wrong population.
Bayer MF, Macoviak JA, McDougall IR. Diagnostic performance of sensitive measurements of serum thyrotropin during severe nonthyroidal illness: their role in the diagnosis of hyperthyroidism. Clin Chem. 1987/12/01. ed1987:2178-84. No relevance to key questions.
Beltran S, Lescure FX, El Esper I, Schmit JL, Desailloud R. Subclinical hypothyroidism in HIV-infected patients is not an autoimmune disease. Horm Res. 2006/05/11. ed2006:21-6. Wrong population.
Bensenor I. Screening for thyroid disorders in asymptomatic adults from Brazilian populations. Sao Paulo Med J. 2002/11/19. ed2002:146-51. No data by design (e.g. opinion, letter, editorial).
Berbel P, Obregon MJ, Bernal J, Escobar del Rey F, Morreale de Escobar G. Iodine supplementation during pregnancy: a public health challenge. Trends Endocrinol Metab. 2007/10/27. ed2007:338-43. Wrong population.
Beyhan Z, Erturk K, Uckaya G, Bolu E, Yaman H, Kutlu M. Restoration of euthyroidism does not improve cardiovascular risk factors in patients with subclinical hypothyroidism in the short term. J Endocrinol Invest. 2006/07/15. ed2006:505-10. No relevance to key questions.
Bhasin S, Enzlin P, Coviello A, Basson R. Sexual dysfunction in men and women with endocrine disorders. Lancet. 2007:597-611. No data by design (e.g. opinion, letter, editorial); Wrong population.
Biondi B. Cardiovascular effects of mild hypothyroidism. Thyroid. 2007:625-30. Background– complications of SCH.
Biondi B, Cooper DS. The clinical significance of subclinical thyroid dysfunction. Endocrine Reviews. 2008:76-131. No data by design (e.g. opinion, letter, editorial).
Biondi B, Klein I. Hypothyroidism as a risk factor for cardiovascular disease. Endocrine. 2004/07/14. ed2004:1-13. No data by design (e.g. opinion, letter, editorial).
Biondi B, Palmieri EA, Klain M, Schlumberger M, Filetti S, Lombardi G. Subclinical hyperthyroidism: clinical features and treatment options. Eur J Endocrinol. 2005/03/15. ed2005:1-9. Wrong population.
Biondi B, Palmieri EA, Lombardi G, Fazio S. Effects of subclinical thyroid dysfunction on the heart. Ann Intern Med. 2002/12/03. ed2002:904-14. No relevance to key questions.
Biondi B, Palmieri EA, Lombardi G, Fazio S. Subclinical hypothyroidism and cardiac function. Thyroid. 2002/08/08. ed2002:505-10. No relevance to key questions.
Bjorndal MM, Sandmo Wilhelmsen K, Lu T, Jorde R. Prevalence and causes of undiagnosed hyperthyroidism in an adult healthy population. The Tromso study. J Endocrinol Invest. 2008/12/19. ed2008:856-60. No relevance to key questions.
Boelaert K, Franklyn JA. Thyroid hormone in health and disease. Journal of Endocrinology. 2005:1-15. No data by design (e.g. opinion, letter, editorial).
Bongiovanni M, Adorni F, Casana M, Tordato F, Tincati C, Cicconi P, et al. Subclinical hypothyroidism in HIV-infected subjects. J Antimicrob Chemother. 2006/09/05. ed2006:1086-9. Wrong population.
Bono G, Fancellu R, Blandini F, Santoro G, Mauri M. Cognitive and affective status in mild hypothyroidism and interactions with L-thyroxine treatment. Acta Neurol Scand. 2004/06/08. ed2004:59-66. Related to topic but does not meet criteria for study design or quality.
Botella-Carretero JI, Gomez-Bueno M, Barrios V, Caballero C, Garcia-Robles R, Sancho J, et al. Chronic thyrotropin-suppressive therapy with levothyroxine and short-term overt hypothyroidism after thyroxine withdrawal are associated with undesirable cardiovascular effects in patients with differentiated thyroid carcinoma. Endocr Relat Cancer. 2004/05/28. ed2004:345-56. No relevance to key questions; Wrong population.
Brenta G, Berg G, Arias P. al.e. Lipoprotein alterations, hepatic lipase activity, and insulin sensitivity in subclinical hypothyroidism: response to L-T4 treatment. Thyroid. 2007:453-60. Related to topic but does not meet criteria for study design or quality.
Burlacu MC, Socin HV, Luyckx F, Beckers A. Subclinical Hypothyroidism: Does TRH Test Help to Narrow Current Reference Ranges?. 32nd Annual Meeting of the European Thyroid Association. Carl Ludwig Institute, University Hospital Leipzig, Leipzig (Germany). 1-5 Sep 2007. 2007:67. Related to topic but does not meet criteria for study design or quality.
Canturk Z, Cetinarslan B, Tarkun I, Canturk NZ, Ozden M. Lipid profile and lipoprotein (a) as a risk factor for cardiovascular disease in women with subclinical hypothyroidism. Endocr Res. 2003/10/11. ed2003:307-16. Related to topic but does not meet criteria for study design or quality.
Caparevic Z, Bojkovic G, Stojanovic D, Ilic V. [Dyslipidemia and subclinical hypothyroidism]. Med Pregl. 2003/10/21. ed2003:276-80. E -does not meet inclusion criteria for study type or quality.
Cappola AR, Fried LP, Arnold AM, Danese MD, Kuller LH, Burke GL, et al. Thyroid status, cardiovascular risk, and mortality in older adults. Jama. 2006:1033-41. Background – complications of SCH.
Caraccio N, Ferrannini E, Monzani F. Lipoprotein profile in subclinical hypothyroidism: response to levothyroxine replacement, a randomized placebo-controlled study. J Clin Endocrinol Metab. 2002/04/05. ed2002:1533-8. Wrong population.
Cardenas-Ibarra L, Solano-Velazquez JA, Salinas-Martinez R, Aspera-Ledezma TD, Sifuentes-Martinez Mdel R, Villarreal-Perez JZ. Cross-sectional observations of thyroid function in geriatric Mexican outpatients with and without dementia. Arch Gerontol Geriatr. 2007/05/22. ed2008:173-80. No relevance to key questions.
Ceresini G, Lauretani F, Maggio M, Ceda GP, Morganti S, Usberti E, et al. Thyroid function abnormalities and cognitive impairment in elderly people: results of the Invecchiare in Chianti study. J Am Geriatr Soc. 2008/12/05. ed2009:89-93. No relevance to key questions.
Cerillo AG, Storti S, Mariani M, Kallushi E, Bevilacqua S, Parri MS, et al. The non-thyroidal illness syndrome after coronary artery bypass grafting: a 6-month follow-up study. Clin Chem Lab Med. 2005/04/22. ed2005:289-93. Wrong population.
Cesur M, Bayram F, Temel MA, Ozkaya M, Kocer A, Ertorer ME, et al. Thyrotoxic hypokalaemic periodic paralysis in a Turkish population: Three new case reports and analysis of the case series. Clinical endocrinology. 2008:143-52. No relevance to key questions.
Chadarevian R, Jublanc C, Bruckert E, Giral P, Ankri A, Leenhardt L, et al. Effect of levothyroxine replacement therapy on coagulation and fibrinolysis in severe hypothyroidism. J Endocrinol Invest. 2005/08/04. ed2005:398-404. No relevance to key questions.
Chen C-H, Chen J-F, Yang B-Y, Liu R-T, Tung S-C, Chien WY, et al. Bone mineral density in women receiving thyroxine suppressive therapy for differentiated thyroid carcinoma. Journal of the Formosan Medical Association. 2004:442-7. Wrong population.
Chen MH, Chen SJ, Su LY, Yang W. Thyroid dysfunction in patients with Down syndrome. Acta Paediatr Taiwan. 2008/02/13. ed2007:191-5. Wrong population.
Chinga-Alayo E, Villena J, Evans A, Zimic M. Thyroid hormone levels improve the prediction of mortality among patients admitted to the intensive care unit. Intensive Care Medicine. 2005:1356-61. Wrong population.
Choi AR, Manning P. Overshooting the mark: subclinical hyperthyroidism secondary to excess thyroid hormone treatment may be more prevalent than we realise. N Z Med J. 2009/03/24. ed2009:93-4. No data by design (e.g. opinion, letter, editorial).
Choi JY, Jang HJ, Park JM, Lee KH, Choi Y, Choe YS, et al. Clinical significance of thyroid visualization on technegas ventilation scintigraphy. Nucl Med Commun. 2004/09/24. ed2004:1015-20. No relevance to key questions.
Christ-Crain M, Meier C, Guglielmetti M, Huber PR, Riesen W, Staub JJ, et al. Elevated C-reactive protein and homocysteine values: cardiovascular risk factors in hypothyroidism? A cross-sectional and a double-blind, placebo-controlled trial. Atherosclerosis. 2003/01/22. ed2003:379-86. No relevance to key questions.
Christ-Crain M, Meier C, Huber PR, Staub JJ, Muller B. Effect of L-thyroxine replacement therapy on surrogate markers of skeletal and cardiac function in subclinical hypothyroidism. Endocrinologist. 2004:161-6. No data by design (e.g. opinion, letter, editorial).
Christ-Crain M, Morgenthaler NG, Meier C, Muller C, Nussbaumer C, Bergmann A, et al. Pro-A-type and N-terminal pro-B-type natriuretic peptides in different thyroid function states. Swiss Med Wkly. 2005/12/08. ed2005:549-54. No relevance to key questions.
Chu JW, Crapo LM. Should mild subclinical hypothyroidism be treated?. Am J Med. 2002/03/21. ed2002:422-3. No data by design (e.g. opinion, letter, editorial).
Chubb SA. Subclinical hypothyroidism and mortality in women with type 2 diabetes. Clinical endocrinology. 2006:476-7. Wrong population.
Chubb SA, Davis WA, Inman Z, Davis TM. Prevalence and progression of subclinical hypothyroidism in women with type 2 diabetes: the Fremantle Diabetes Study. Clin Endocrinol (Oxf). Aprinitial search 6/11/09. 2005;62(4):480-6. Wrong population. [pmid: 15807880].
Cinemre H, Bilir C, Gokosmanoglu F, Bahcebasi T. Hematologic effects of levothyroxine in iron-deficient subclinical hypothyroid patients: a randomized, double-blind, controlled study. J Clin Endocrinol Metab. 2008/11/06. ed2009:151-6. Wrong population.
Cleary-Goldman J, Malone FD, Lambert-Messerlian G, Sullivan L, Canick J, Porter TF, et al. Maternal thyroid hypofunction and pregnancy outcome. Obstet Gynecol. 2008/07/02. ed2008:85-92. Wrong population.
Col NF, Surks MI, Daniels GH. Subclinical Thyroid Disease: Clinical Applications. Journal of the American Medical Association. 2004:239-43. Background -review.
Coll PP, Taxel P. The Management of Thyroid Disorders in Long-Term Care. Annals of Long-Term Care. 2004:26-30. Wrong population.
Colleran KM, Romero LA, Upton DA, Burge MR. Methimazole-induced hypothyroidism paradoxically decreases homocysteine. Metabolism. 2005/03/31. ed2005:460-5. Wrong population; No relevance to key questions.
Cooper D, Halpern RF, Wood L, Levin A, Ridgway E. L-Thyroxine therapy in subclinical hypothyroidism. A double-blind, placebo-controlled trial. Ann Intern Med. 1984:18-24. Related to topic but does not meet criteria for study design or quality.
Cooper DS. Clinical Practice: Subclinical Hypothyroidism. N Engl J Med. 2001:260-5. Background -review.
Cooper DS. Thyroid Disease in the Oldest Old: The Exception to the Rule. Jama. 2004:2651-4. Background – effect of elevated TSH.
Cooper DS. Approach to the patient with subclinical hyperthyroidism. J Clin Endocrinol Metab. 2007/01/09. ed2007:3-9. Background -review.
Correia N, Mullally S, Cooke G, Tun TK, Phelan N, Feeney J, et al. Evidence for a specific defect in hippocampal memory in overt and subclinical hypothyroidism. J Clin Endocrinol Metab. 2009/07/09. ed2009:3789-97. Related to topic but does not meet criteria for study design or quality.
Dardano A, Monzani F. Hypothyroidism and endothelial function: A marker of early atherosclerosis?. Recent Patents on Endocrine, Metabolic and Immune Drug Discovery. 2008:79-96. No data by design (e.g. opinion, letter, editorial).
Dashe JF, Cunningham FG. Subclinical hypothyroidism. New England Journal of Medicine. 2001:1855-6. No data by design (e.g. opinion, letter, editorial).
Davis JD, Tremont G. Neuropsychiatric aspects of hypothyroidism and treatment reversibility. Minerva Endocrinol. 2007/03/14. ed2007:49-65. No data by design (e.g. opinion, letter, editorial).
DeBoer MD, LaFranchi S. Differential presentation for children with autoimmune thyroiditis discovered because of symptom development or screening. J Pediatr Endocrinol Metab. 2008/10/02. ed2008:753-61. Wrong population.
Dederichs B, Dietlein M, Jenniches-Kloth B, Schmidt M, Theissen P, Moka D, et al. Radioiodine therapy of Graves' hyperthyroidism in patients without pre-existing ophthalmopathy: can glucocorticoids prevent the development of new ophthalmopathy?. Exp Clin Endocrinol Diabetes. 2006/08/18. ed2006:366-70. Wrong population.
Devdhar M, Ousman YH, Burman KD. Hypothyroidism. Endocrinol Metab Clin North Am. 2007/08/04. ed2007:595-615. v. No relevance to key questions.
Diez JJ, Iglesias P. Subclinical hypothyroidism in women with type 2 diabetes. Clin Endocrinol (Oxf). 2005/09/27. ed2005:479-80. No data by design (e.g. opinion, letter, editorial).
Diez JJ, Iglesias P, Burman KD. Spontaneous Normalization of Thyrotropin Concentrations in Patients with Subclinical Hypothyroidism. J Clin Endocrinol Metab. 2005:4124-7. No relevance to key questions.
Djezairi AH. Subclinical Hypothyroidism in Older Patients: An Analysis of Natural Course and Risk Factors for the Thyroid Failure. 2008. 10th European Congress of Endocrinology (ECE 2008). Berlin (Germany). 3-7 May 2008. No relevance to key questions.
Dominguez LJ, Bevilacqua M, DiBella G, Barbagallo M. Diagnosing and Managing Thyroid Disease in the Nursing Home. Journal of the American Medical Directors Association. 2008:9-17. Wrong population.
Dossing H, Bennedbaek FN, Bonnema SJ, Grupe P, Hegedus L. Randomized prospective study comparing a single radioiodine dose and a single laser therapy session in autonomously functioning thyroid nodules. Eur J Endocrinol. 2007/07/05. ed2007:95-100. Wrong population.
Duggal J, Singh S, Barsano CP, Arora R. Cardiovascular risk with subclinical hyperthyroidism and hypothyroidism: pathophysiology and management. J Cardiometab Syndr. 2007/09/06. ed2007:198-206. No data by design (e.g. opinion, letter, editorial).
Duman D, Demirtunc R, Sahin S, Esertas K. The effects of simvastatin and levothyroxine on intima-media thickness of the carotid artery in female normolipemic patients with subclinical hypothyroidism: a prospective, randomized-controlled study. J Cardiovasc Med (Hagerstown). 2007/12/29. ed2007:1007-11. Related to topic but does not meet criteria for study design or quality.
Duman D, Sahin S, Esertas K, Demirtunc R. Simvastatin improves endothelial function in patents with subclinical hypothyroidism. Heart Vessels. 2007/03/29. ed2007:88-93. Related to topic but does not meet criteria for study design or quality.
Duntas LH, Wartofsky L. Cardiovascular risk and subclinical hypothyroidism: focus on lipids and new emerging risk factors. What is the evidence?. Thyroid. 2007/09/29. ed2007:1075-84. No relevance to key questions; No data by design (e.g. opinion, letter, editorial).
Eftekhari M, Asadollahi A, Beiki D, Izadyar S, Gholamrezanezhad A, Assadi M, et al. The long term effect of levothyroxine on bone mineral density in patients with well differentiated thyroid carcinoma after treatment. Hellenic Journal of Nuclear Medicine. 2008:160-3. Wrong population.
Eldar-Geva T, Shoham M, Rosler A, Margalioth EJ, Livne K, Meirow D. Subclinical hypothyroidism in infertile women: the importance of continuous monitoring and the role of the thyrotropin-releasing hormone stimulation test. Gynecol Endocrinol. 2007/07/10. ed2007:332-7. No relevance to key questions.
Enia G, Panuccio V, Cutrupi S, Pizzini P, Tripepi G, Mallamaci F, et al. Subclinical hypothyroidism is linked to micro-inflammation and predicts death in continuous ambulatory peritoneal dialysis. Nephrol Dial Transplant. 2007:538-44. Wrong population.
Erdal M, Sahin M, Saglam K, Hasimi A, Uckaya G, Yarpuz MY, et al. Increased serum chitotriosidase activity following restoration of euthyroidism in patients with subclinical hypothyroidism. Intern Med. 2008/07/17. ed2008:1309-14. Related to topic but does not meet criteria for study design or quality.
Eustatia-Rutten CF, Corssmit EP, Pereira AM, Frolich M, Bax JJ, Romijn JA, et al. Quality of life in longterm exogenous subclinical hyperthyroidism and the effects of restoration of euthyroidism, a randomized controlled trial. Clin Endocrinol (Oxf). 2006/02/21. ed2006:284-91. Wrong population.
Eyal O, Blum S, Mueller R, Smith FO, Rose SR. Improved growth velocity during thyroid hormone therapy in children with Fanconi anemia and borderline thyroid function. Pediatr Blood Cancer. 2008/07/16. ed2008:652-6. Wrong population.
Fadeyev VV, Sytch J, Kalashnikov V, Rojtman A, Syrkin A, Melnichenko G. Levothyroxine replacement therapy in patients with subclinical hypothyroidism and coronary artery disease. Endocr Pract. 2006/03/10. ed2006:5-17. Wrong population.
Falaschi P, Martocchia A, Proietti A, D'Urso R, Gargano S, Culasso F, et al. The hypothalamic-pituitary-thyroid axis in subjects with subclinical thyroid diseases: the impact of the negative feedback mechanism. Neuro endocrinology letters. 2004:292-6. No relevance to key questions.
Fatourechi V. Subclinical hypothyroidism: When to treat, when to watch?. Consultant. 2004:533-9. No data by design (e.g. opinion, letter, editorial).
Fatourechi V. Subclinical hypothyroidism: Why wait to treat?. Consultant. 2004:904. %N 7. No data by design (e.g. opinion, letter, editorial).
Fatourechi V. Subclinical hypothyroidism: an update for primary care physicians. Mayo Clin Proc. 2009/01/06. ed2009:65-71. No data by design (e.g. opinion, letter, editorial).
Fatourechi V, Klee GG, Grebe SK, Bahn RS, Brennan MD, Hay ID, et al. Effects of Reducing the Upper Limit of Normal TSH Values. JAMA. 2003:3195-6. No relevance to key questions.
Fatourechi V, Lankarani M, Schryver PG, Vanness DJ, Long KH, Klee GG. Factors influencing clinical decisions to initiate thyroxine therapy for patients with mildly increased serum thyrotropin (5.1-10.0 mIU/L). Mayo Clin Proc. 2003/05/15. ed2003:554-60. No relevance to key questions.
Fazio S, Palmieri EA, Lombardi G, Biondi B. Effects of thyroid hormone on the cardiovascular system. Recent Prog Horm Res. 2004/01/30. ed2004:31-50. No data by design (e.g. opinion, letter, editorial).
FDA. Medical Review for Levothyroxine Sodium (Unithroid). 2000. No data (e.g. description of study only).
FDA. Medical Review for Levothyroxine Sodium (Levoxyl). 2001. No data (e.g. description of study only).
FDA. Medical Review for Levothyroxine Sodium (Levo-T). 2002. No data (e.g. description of study only).
FDA. Medical Review for Levothyroxine Sodium (Novothyrox). 2002. No data (e.g. description of study only).
FDA. Medical Review for Levothyroxine Sodium (Synthroid). 2002. No data (e.g. description of study only).
FDA. Medical Review for Levothyroxine Sodium (Thyro-Tabs). 2002. No data (e.g. description of study only).
FDA. Medical Review for Levothyroxine Sodium (Levolet). 2003. No data (e.g. description of study only).
FDA. Medical Review for Levothyroxine Sodium (Triosint). 2006. No data (e.g. description of study only).
FDA. Medical Review for Levothyroxine Sodium (Tirosint). 2007. No data (e.g. description of study only).
Fiarresga AJ, Feliciano J, Fernandes R, Martins A, Pelicano N, Timoteo AT, et al. Relationship between coronary disease and subclinical hypothyroidism: an angiographic study. Rev Port Cardiol. 2009:535-43. Wrong population.
Filippatos TD, Derdemezis CS, Gazi IF, Nakou ES, Mikhailidis DP, Elisaf MS. Orlistat-associated adverse effects and drug interactions: A critical review. Drug Safety. 2008:53-65. No relevance to key questions.
Flynn RWV, MacDonald TM, Jung RT, Morris AD, Leese GP. Mortality and Vascular Outcomes in Patients Treated for Thyroid Dysfunction. J Clin Endocrinol Metab. 2006:2159-64. Wrong population.
Fowler PB. Mortality in elderly patients with subclinical hyperthyroidism. Lancet. 2002/03/13. ed2002:798. author reply 9. No data by design (e.g. opinion, letter, editorial).
Franklyn JA. Subclinical thyroid disorders-consequences and implications for treatment. Ann Endocrinol (Paris). 2007/07/27. ed2007:229-30. No data by design (e.g. opinion, letter, editorial).
Franzoni F, Galetta F, Fallahi P, Tocchini L, Merico G, Braccini L, et al. Effect of L-thyroxine treatment on left ventricular function in subclinical hypothyroidism. Biomed Pharmacother. 2006/08/29. ed2006:431-6. No relevance to key questions.
Fraser SA, Kroenke K, Callahan CM, Hui SL, Williams JW, Unutzer J. Low yield of thyroid-stimulating hormone testing in elderly patients with depression. General Hospital Psychiatry. 2004:302-9. No relevance to key questions.
Freitas MCd, Campolina AG, Ribeiro RL, Kitadai FT. Comparação de função cognitiva e depressão em pacientes hipotireoideos subclínicos com eutiroideos e hipotireoideos em tratamento, acima de 65 anos. Comparison of cognitive function and depression among patients over 65 years in subclinical hypothyroidism, euthyroidism and hypotyroidism in treatment. Rev Soc Bras Clín Méd. 2009. Not related to key questions.
Galetta F, Franzoni F, Fallahi P, Rossi M, Carpi A, Rubello D, et al. Heart rate variability and QT dispersion in patients with subclinical hypothyroidism. Biomed Pharmacother. 2006/08/26. ed2006:425-30. No relevance to key questions.
Gammage MD, Parle JV, Holder RL, Roberts LM, Hobbs FDR, Wilson S, et al. Association between serum free thyroxine concentration and atrial fibrillation. Archives of Internal Medicine. 2007:928-34. No relevance to key questions.
Ganotakis ES, Mandalaki K, Tampakaki M, Malliaraki N, Mandalakis E, Vrentzos G, et al. Subclinical hypothyroidism and lipid abnormalities in older women attending a vascular disease prevention clinic: effect of thyroid replacement therapy. Angiology. 2003/10/21. ed2003:569-76. Related to topic but does not meet criteria for study design or quality.
Gharib H, Tuttle R, Baskin H, Fish L, Singer P, MT M. Subclinical thyroid dysfunction: a joint statement on management from the American Association of Clinical Endocrinologists, the American Thyroid Association, and the Endocrine Society. Thyroid. 2005:24-8. Background -review.
Gharib H, Tuttle RM, Baskin HJ, Fish LH, Singer PA, McDermott MT. Consensus Statement #1: Subclinical thyroid dysfunction: a joint statement on management from the American Association of Clinical Endocrinologists, the American Thyroid Association, and The Endocrine Society. Thyroid. 2005:963-9. Background -review.
Ghita S, Musat M, Simescu M, Balmes E, Ursu H, Badiu C, et al. Subclinical Hypothyroidism How Soon to Treat?. 2006. 8th European Congress of Endocrinology (ECE 2006). SECC Congress Centre, Glasgow, Scotland (UK). 1-5 Apr 2006. Related to topic but does not meet criteria for study design or quality.
Gjedde S, Vestergaard ET, Gormsen LC, Riis AL, Rungby J, Moller N, et al. Serum ghrelin levels are increased in hypothyroid patients and become normalized by L-thyroxine treatment. J Clin Endocrinol Metab. 2008;93(6):2277-80. Juninitial search 6/11/09. No relevance to key questions. [pmid: 18381578].
Guldiken S, Demir M, Turgut B, Altun BU, Arikan E, Kara M. Global Fibrinolytic Capacity in Patients with Subclinical Hypothyroidism. Endocr J. 2005:363-7. No relevance to key questions.
Gullu S, Altuntas F, Dincer I, Erol C, Kamel N. Effects of TSH-suppressive therapy on cardiac morphology and function: beneficial effects of the addition of beta-blockade on diastolic dysfunction. Eur J Endocrinol. 2004:655-61. Wrong population.
Gullu S, Sav H, Kamel N. Effects of levothyroxine treatment on biochemical and hemostasis parameters in patients with hypothyroidism. Eur J Endocrinol. 2005/03/11. ed2005:355-61. No relevance to key questions; Wrong population.
Gulseren S, Gulseren L, Hekimsoy Z, Cetinay P, Ozen C, Tokatlioglu B. Depression, Anxiety, Health-Related Quality of Life, and Disability in Patients with Overt and Subclinical Thyroid Dysfunction. Archives of Medical Research. 2006:133-9. Related to topic but does not meet criteria for study design or quality.
Hamano K, Inoue M. Increased risk for atherosclerosis estimated by pulse wave velocity in hypothyroidism and its reversal with appropriate thyroxine treatment. Endocr J. 2005/03/11. ed2005:95-101. No relevance to key questions.
Handisurya A, Pacini G, Tura A, Gessl A, Kautzky-Willer A. Effects of T4 replacement therapy on glucose metabolism in subjects with subclinical (SH) and overt hypothyroidism (OH). Clinical endocrinology. 2008:963-9. No relevance to key questions.
Hasanhodzic M, Tahirovic H, Lukinac L. Down Syndrome and thyroid gland. Bosn J Basic Med Sci. 2006/09/26. ed2006:38-42. No relevance to key questions.
Health Canada Apotex Inc. Product Monograpy APO-Methimazole. 2004. No data by design (e.g. opinion, letter, editorial).
Health Canada EMD Serono Canada. Product Monograph Euthyrox. 2008. No data by design (e.g. opinion, letter, editorial).
Heemstra KA, Hamdy NA, Romijn JA, Smit JW. The effects of thyrotropin-suppressive therapy on bone metabolism in patients with well-differentiated thyroid carcinoma. Thyroid. 2006/07/15. ed2006:583-91. Wrong population.
Heemstra KA, Smit JW, Eustatia-Rutten CF, Heijboer AC, Frolich M, Romijn JA, et al. Glucose tolerance and lipid profile in longterm exogenous subclinical hyperthyroidism and the effects of restoration of euthyroidism, a randomised controlled trial. Clin Endocrinol (Oxf). 2006/11/24. ed2006:737-44. Wrong population.
Helfand M. Screening for subclinical thyroid dysfunction in nonpregnant adults: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2004:128-41. Background -review.
Ho AC, Ho WK, Lam PK, Yuen AP, Wei WI. Thyroid dysfunction in laryngectomees-10 years after treatment. Head Neck. 2007/07/20. ed2008:336-40. No relevance to key questions.
Hoffmann CJ, Brown TT. Thyroid function abnormalities in HIV-infected patients. Clin Infect Dis. 2007/07/20. ed2007:488-94. No data by design (e.g. opinion, letter, editorial).
Hogervorst E, Huppert F, Matthews FE, Brayne C. Thyroid function and cognitive decline in the MRC Cognitive Function and Ageing Study. Psychoneuroendocrinology. 2008/07/22. ed2008:1013-22. No relevance to key questions.
Hoogendoorn EH, den Heijer M, van Dijk AP, Hermus AR. Subclinical hyperthyroidism: to treat or not to treat?. Postgrad Med J. 2004/07/16. ed2004:394-8. No data by design (e.g. opinion, letter, editorial).
Hoogendoorn EH, Wiersinga WM, Prummel MF, den Heijer M, Corstens FH, Hermus AR. [Subclinical hypothyroidism; the start of a clinical trial into the usefulness of treatment with radioactive iodine]. article in Dutch. Ned Tijdschr Geneeskd. 2004/05/27. ed2004:953-4. No data by design.
Hoogendoorn EH, Hermus AR, de Vegt F, Ross HA, Verbeek AL, Kiemeney LA, et al. Thyroid function and prevalence of anti-thyroperoxidase antibodies in a population with borderline sufficient iodine intake: influences of age and sex. Clin Chem. 2005/10/29. ed2006:104-11. No relevance to key questions.
Iacoviello M, Guida P, Guastamacchia E, Triggiani V, Forleo C, Catanzaro R, et al. Prognostic role of sub-clinical hypothyroidism in chronic heart failure outpatients. Curr Pharm Des. 2008/11/15. ed2008:2686-92. No relevance to key questions; Wrong population.
Iglesias P, Munoz A, Prado F, Guerrero MT, Macias MC, Ridruejo E, et al. Alterations in thyroid function tests in aged hospitalized patients: prevalence, aetiology and clinical outcome. Clinical endocrinology. 2009:961-7. Wrong population.
Imaizumi M, Akahoshi M, Ichimaru S, Nakashima E, Hida A, Soda M, et al. Risk for ischemic heart disease and all-cause mortality in subclinical hypothyroidism. J Clin Endocrinol Metab. 2004/07/09. ed2004:3365-70. No relevance to key questions.
Ineck BA, Ng TM. Effects of subclinical hypothyroidism and its treatment on serum lipids. Ann Pharmacother. 2003/04/24. ed2003:725-30. No data by design (e.g. opinion, letter, editorial).
Ishay A, Chertok-Shaham I, Lavi I, Luboshitzky R. Prevalence of subclinical hypothyroidism in women with type 2 diabetes. Med Sci Monit. 2009/04/01. ed2009:CR151-5. No relevance to key questions.
Ishiguro H, Yasuda Y, Tomita Y, Shinagawa T, Shimizu T, Morimoto T, et al. Long-term follow-up of thyroid function in patients who received bone marrow transplantation during childhood and adolescence. J Clin Endocrinol Metab. 2004/12/08. ed2004:5981-6. No relevance to key questions.
ISRCTN35570362. The cardiovascular risk in people with SCH, health status and quality of life can be improved by treatment with L-thyroxine. No data (e.g. description of study only).
ISRCTN52563354. The effects of a 12-week exercise intervention on respiratory exchange ratio, body composition, thyroid function and lipid metabolism in hypothyroid, obese women. Wrong population.
Jensovsky J, Ruzicka E, Spackova N, Hejdukova B. Changes of event related potential and cognitive processes in patients with subclinical hypothyroidism after thyroxine treatment. Endocr Regul. 2002/12/05. ed2002:115-22. Wrong population.
Jublanc C, Bruckert E. Hypothyroidism and cardiovascular disease: role of new risk factors and coagulation parameters. Semin Vasc Med. 2004/10/13. ed2004:145-51. No relevance to key questions.
Kafilmout I, Morris LD, Mayer J. What causes a low TSH level with a normal free T4 level?. Journal of Family Practice. 2006:543-4. Background – effect of elevated TSH.
Kalantari S, Heidarzadeh A. Thyroxine therapy improves serum lipoproteins and some clinical findings in patients with subclinical hypothyroidism. Related to topic but does not meet criteria for study design or quality.
Karlin NJ, Weintraub N, Chopra IJ. Current controversies in endocrinology: screening of asymptomatic elderly for subclinical hypothyroidism. J Am Med Dir Assoc. 2004/09/11. ed2004:333-6. No data by design (e.g. opinion, letter, editorial).
Karmisholt J, Andersen S, Laurberg P. Variation in thyroid function tests in patients with stable untreated subclinical hypothyroidism. Thyroid. 2008:303-8. No relevance to key questions.
Karmisholt J, Laurberg P. Serum-TSH and Serum-TPO-Ab Oscillate in Parallel and High Urinary Iodine Excretion (UIE) Predicts Subsequent Thyroid Failure. A One Year Study of Patients with Untreated Subclinical Hypothyroidism (SH). 32nd Annual Meeting of the European Thyroid Association. Carl Ludwig Institute, University Hospital Leipzig, Leipzig (Germany). 1-5 Sep 2007. 2007:69. No relevance to key questions; Related to topic but does not meet criteria for study design or quality.
Kebapcilar L, Comlekci A, Tuncel P, Solak A, Secil M, Gencel O, et al. The Effects of Subclinical Hypothyroidism and Replacement Therapy on Paraoxonase-1 (PON-1) and Common Carotis Intima Media Thickness. 2007. 9th European Congress of Endocrinology (ECE 2007). Budapest (Hungary). 28 Apr-2 May 2007. No relevance to key questions; Related to topic but does not meet criteria for study design or quality.
Khalife WI, Tang YD, Kuzman JA, Thomas TA, Anderson BE, Said S, et al. Treatment of subclinical hypothyroidism reverses ischemia and prevents myocyte loss and progressive LV dysfunction in hamsters with dilated cardiomyopathy. Am J Physiol Heart Circ Physiol. 2005/07/19. ed2005:H2409-15. Wrong population.
Kim DD, Young S, Cutfield R. A survey of thyroid function test abnormalities in patients presenting with atrial fibrillation and flutter to a New Zealand district hospital. N Z Med J. 2008/12/17. ed2008:82-6. No relevance to key questions.
Kim SK, Kim SH, Park KS, Park SW, Cho YW. Regression of the increased common carotid artery-intima media thickness in subclinical hypothyroidism after thyroid hormone replacement. Endocr J. 2009. Related to topic but does not meet criteria for study design or quality.
King Pharmaceuticals. No data (e.g. description of study only).
Kok P, Roelfsema F, Langendonk JG, Frolich M, Burggraaf J, Meinders AE, et al. High circulating thyrotropin levels in obese women are reduced after body weight loss induced by caloric restriction. The Journal of clinical endocrinology and metabolism. 2005:4659-63. No relevance to key questions.
Kong WM, Sheikh MH, Lumb PJ, Naoumova RP, Freedman DB, Crook M, et al. A 6-month randomized trial of thyroxine treatment in women with mild subclinical hypothyroidism. Am J Med. 2002/03/21. ed2002:348-54. Related to topic but does not meet criteria for study design or quality.
Koral L, Hekimsoy Z, Yildirim C, Ozmen B, Yorgancioglu A, Girgin A. Does thyroid replacement therapy affect pulmonary function tests in patients with subclinical hypothyroidism?. Saudi Med J. 2006:329-332. Related to topic but does not meet criteria for study design or quality.
Koren Peleg R. al. e. The effect of levothyroxine on arterial stiffness and lipid profile in patients with sublinical hypothyroidism. Thyroid. 2008:825-30. Related to topic but does not meet criteria for study design or quality.
Kraft O, Stepien A. Functional autonomies of thyroid and efficacy of radioiodine therapy. Cancer Biother Radiopharm. 2007/06/30. ed2007:261-7. Wrong population.
Krausz Y, Freedman N, Lester H, Newman JP, Barkai G, Bocher M, et al. Regional cerebral blood flow in patients with mild hypothyroidism. J Nucl Med. 2004/10/09. ed2004:1712-5. Wrong population.
Kumar A, Chaturvedi PK, Mohanty BP. Hypoandrogenaemia is associated with subclinical hypothyroidism in men. Int J Androl. 2006/08/02. ed2007:14-20. No relevance to key questions.
Larisch R, Kley K, Nikolaus S, Sitte W, Franz M, Hautzel H, et al. Depression and anxiety in different thyroid function states. Horm Metab Res. 2004/10/16. ed2004:650-3. Background – complications of SCH.
Laurberg P, Andersen S, Bulow Pedersen I, Carle A. Hypothyroidism in the elderly: pathophysiology, diagnosis and treatment. Drugs Aging. 2005/01/25. ed2005:23-38. No data by design (e.g. opinion, letter, editorial).
Laurberg P, Pedersen IB. Measurements of TSH receptor antibodies in differential diagnosis. Immuno-Analyse et Biologie Specialisee. 2006:234-8. No relevance to key questions.
Lazarus JH. Aspects of treatment of subclinical hypothyroidism. Thyroid. 2007/05/01. ed2007:313-6. No data by design (e.g. opinion, letter, editorial).
LeGrys VA, Hartmann K, Walsh JF. The clinical consequences and diagnosis of hypothyroidism. Clin Lab Sci. 2004/11/24. ed2004:203-8. No data by design (e.g. opinion, letter, editorial).
Lin TH, Su HM, Voon WC, Lai WT, Sheu SH. Unstable angina with normal coronary angiography in hyperthyroidism: a case report. Kaohsiung J Med Sci. 2005/03/10. ed2005:29-33. No data by design (e.g. opinion, letter, editorial).
Liu Y, Redetzke RA, Said S, Pottala JV, de Escobar GM, Gerdes AM. Serum thyroid hormone levels may not accurately reflect thyroid tissue levels and cardiac function in mild hypothyroidism. Am J Physiol Heart Circ Physiol. 2008/03/04. ed2008:H2137-43. Wrong population.
Lock RJ, Marden NA, Kemp HJ, Thomas PH, Goldie DJ, Gompels MM. Subclinical hypothyroidism: a comparison of strategies to achieve adherence to treatment guidelines. Ann Clin Biochem. 2004/05/01. ed2004:197-200. No relevance to key questions; Wrong population and No relevance to key questions.
Luboshitzky R, Herer P. Cardiovascular risk factors in middle-aged women with subclinical hypothyroidism. Neuroendocrinology letters. 2004:262-6. B/ No relevance to key questions.
Macedo CG, Mamede FBV, Oliveira FvRd, Gomes JD, Moreira LA, Marino MÃnZ, et al. InfluÃªncia do hipotireoidismo subclÃnico em pacientes com hipercolesterolemia; Influence ofsubclinical hypothyreoidism in patients with hypercholesterolemia. Arq mÃ©d ABC. 2004:37-43. Related to topic but does not meet criteria for study design or quality.
Madge S, Smith CJ, Lampe FC, Thomas M, Johnson MA, Youle M, et al. No association between HIV disease and its treatment and thyroid function. HIV Medicine. 2007:22-7. Wrong population; No relevance to key questions.
Marina L, Vujovic S, Ivovic M, Tancic-Gajic M, Stojanovic M, Barac M, et al. Surprising: Hyperlipidemia in Subclinical Hyperthyroidism!. 2008. 10th European Congress of Endocrinology (ECE 2008). Berlin (Germany). 3-7 May 2008. No relevance to key questions.
Mariotti S, Cambuli VM. Cardiovascular risk in elderly hypothyroid patients. Thyroid. 2007/12/01. ed2007:1067-73. No data by design (e.g. opinion, letter, editorial).
Mariotti S, Zoncu S, Pigliaru F, Putzu C, Cambuli VM, Vargiu S, et al. Cardiac effects of L-thyroxine administration in borderline hypothyroidism. Int J Cardiol. 2007/05/15. ed2008:190-5. Wrong population and No relevance to key questions.
Martinez I, Giralt P. Subclinical Hyperthyroidism, a Retrospective Study for 11 Years. 2008. 10th European Congress of Endocrinology (ECE 2008). Berlin (Germany). 3-7 May 2008. Related to topic but does not meet criteria for study design or quality.
Martin-Ezquerra G, Sanchez-Regana M, Massana-Gil J, Umbert-Millet P. Papular mucinosis associated with subclinical hypothyroidism: improvement with thyroxine therapy. J Eur Acad Dermatol Venereol. 2006/10/26. ed2006:1340-1. No data by design (e.g. opinion, letter, editorial); No relevance to key questions.
McCormack AI, Learoyd DL. A guide to thyroid dysfunction. Medicine Today. 2006:28-35. No data by design (e.g. opinion, letter, editorial).
McMillan C, Bradley C, Razvi S, Weaver J. Evaluation of new measures of the impact of hypothyroidism on quality of life and symptoms: the ThyDQoL and ThySRQ. Value Health. 2008/04/03. ed2008:285-94. No relevance to key questions.
Meek S, Smallridge RC. Effect of thyroid hormone replacement on methionine-stimulated homocysteine levels in patients with subclinical hypothyroidism: a randomized, double-blind, placebo-controlled study. Endocr Pract. 2006/09/28. ed2006:529-34. No relevance to key questions.
Meier C, Beat M, Guglielmetti M, Christ-Crain M, Staub JJ, Kraenzlin M. Restoration of euthyroidism accelerates bone turnover in patients with subclinical hypothyroidism: a randomized controlled trial. Osteoporos Int. 2004/01/17. ed2004:209-16. Wrong population.
Metso S, Jaatinen P, Huhtala H, Auvinen A, Oksala H, Salmi J. Increased Cardiovascular and Cancer Mortality after Radioiodine Treatment for Hyperthyroidism. J Clin Endocrinol Metab. 2007:2190-6. Wrong population.
Milionis H, Tambaki A, Kanioglou C. al. e. Thyroid substitution therapy induces high density lipoprotein-associated platelet-activating factor acetylhydrolase in patients with sub-clinical hypothyroidism: a potential antiatherogenic effect. Thyroid. 2005:455-60. Related to topic but does not meet criteria for study design or quality.
Mishra TK, Routray SN, Das S, Behera M. Left ventricular dysfunction in patients with subclinical hypothyroidism and its reversibility after hormone therapy. J Assoc Physicians India. 2006/03/07. ed2005:943-6. No relevance to key questions.
Monzani F, Caraccio N, Kozakowa M, Dardano A, Vittone F, Virdis A, et al. Effect of levothyroxine replacement on lipid profile and intima-media thickness in subclinical hypothyroidism: a double-blind, placebo-controlled study. J Clin Endocrinol Metab. 2004/05/06. ed2004:2099-106. Wrong population.
Monzani F, Dardano A, Caraccio N. Does treating subclinical hypothyroidism improve markers of cardiovascular risk?. Treat Endocrinol. 2006/03/18. ed2006:65-81. No relevance to key questions.
Moradi S, Bahreinian AM, Azizi F. The effects of L-thyroxine treatment on cognitive and psychiatric aspects of subclinical hypothyroidism: a randomized, double blind clinical trial [Farsi]. Journal of Iran University of Medical Sciences. 2005:174. Related to topic but does not meet criteria for study design or quality.
Morocco M, Kloss RT. Subclinical hypothyroidism in women: who to treat. Dis Mon. 2003/02/04. ed2002:659-70. No data by design (e.g. opinion, letter, editorial).
Morote J, Esquena S, Orsola A, Salvador C, Trilla E, Cecchini L, et al. Effect of androgen deprivation therapy in the thyroid function test of patients with prostate cancer. Anti-Cancer Drugs. 2005:863-6. No relevance to key questions.
Nakayama Y, Ohno M, Yonemura S, Uozumi H, Kobayakawa N, Fukushima K, et al. A case of transient 2:1 atrioventricular block, resolved by thyroxine supplementation for subclinical hypothyroidism. Pacing Clin Electrophysiol. 2006/01/31. ed2006:106-8. Wrong population.
NCT00094237. Subclinical Thyroid Dysfunction and Risk of Myocardial Infarction and Stroke. Related to topic but does not meet criteria for study design or quality.
NCT00497575. Diagnosis and Follow-up of Patients With Subclinical Hypothyroidism (CHRO1). Wrong population.
NCT00498238. The Effect of Levothyroxine on Arterial Stiffness and Lipid Profile in Patients With Subclinical Hypothyroidism. No data (e.g. description of study only).
Nelson M, Hercbergs A, Rybicki L, Strome M. Association Between Development of Hypothyroidism and Improved Survival in Patients With Head and Neck Cancer. Arch Otolaryngol Head Neck Surg. 2006:1041-6. Wrong population.
Nyirenda MJ, Clark DN, Finlayson AR, Read J, Elders A, Bain M, et al. Thyroid Disease and Increased Cardiovascular Risk. Thyroid. 2005:718-24. Wrong population; No relevance to key questions.
Ochs N, Auer R, Bauer DC, Nanchen D, Gussekloo J, Cornuz J, et al. Meta-analysis: subclinical thyroid dysfunction and the risk for coronary heart disease and mortality. Ann Intern Med. 2008/05/21. ed2008:832-45. Wrong population; No relevance to key questions); No data by design (e.g. opinion, letter, editorial).
Oflaz H, Kurt R, Sen F, Onur I, Cimen AO, Elitok A, et al. Coronary flow reserve after L-thyroxine therapy in Hashimoto's thyroiditis patients with subclinical and overt hypothyroidism. Endocrine. 2008/01/29. ed2007:264-70. Related to topic but does not meet criteria for study design or quality.
Osman F, Franklyn JA, Daykin J, Chowdhary S, Holder RL, Sheppard MC, et al. Heart rate variability and turbulence in hyperthyroidism before, during, and after treatment. Am J Cardiol. 2004/08/25. ed2004:465-9. Wrong population.
O'Sullivan AJ, Lewis M, Diamond T. Amiodarone-induced thyrotoxicosis: left ventricular dysfunction is associated with increased mortality. Eur J Endocrinol. 2006:533-6. Wrong population.
Ovadia S, Lysyy L, Zubkov T. Pericardial effusion as an expression of thyrotoxicosis. Tex Heart Inst J. 2007/04/11. ed2007:88-90. No relevance to key questions; Wrong population.
Ozcan O, Cakir E, Yaman H, Akgul EO, Erturk K, Beyhan Z, et al. The effects of thyroxine replacement on the levels of serum asymmetric dimethylarginine (ADMA) and other biochemical cardiovascular risk markers in patients with subclinical hypothyroidism. Clin Endocrinol (Oxf). 2005/08/03. ed2005:203-6. Wrong population.
Pagano L, Pulcrano M, Ippolito S, Rossi A, rrico A, Sidiropulos M, et al. Coronary Flow Reserve (CFR) in Patients with Subclinical Hypothyroidism. 32nd Annual Meeting of the European Thyroid Association. Carl Ludwig Institute, University Hospital Leipzig, Leipzig (Germany). 1-5 Sep 2007. 2007:90. No relevance to key questions.
Palmieri EA, Fazio S, Lombardi G, Biondi B. Subclinical hypothyroidism and cardiovascular risk: a reason to treat?. Treat Endocrinol. 2005/07/20. ed2004:233-44. No data by design (e.g. opinion, letter, editorial).
Papi G, Pearce EN, Braverman LE, Betterle C, Roti E. A clinical and therapeutic approach to thyrotoxicosis with thyroid-stimulating hormone suppression only. American Journal of Medicine. 2005:349-61. No relevance to key questions.
Papi G, Uberti ED, Betterle C, Carani C, Pearce EN, Braverman LE, et al. Subclinical hypothyroidism. Curr Opin Endocrinol Diabetes Obes. 2007/10/18. ed2007:197-208. Background -review.
Park YJ, Yoon JW, Kim KI, Lee YJ, Kim KW, Choi SH, et al. Subclinical hypothyroidism might increase the risk of transient atrial fibrillation after coronary artery bypass grafting. Ann Thorac Surg. 2009/05/26. ed2009:1846-52. Wrong population.
Parker L. Subclinical hyperthyroidism. N Engl J Med. 2002/01/05. ed2002:67-8. No data by design (e.g. opinion, letter, editorial).
Paz-Filho GJ, Graf H. Recombinant human thyrotropin in the management of thyroid disorders. Expert Opinion on Biological Therapy. 2008:1721-32. No relevance to key questions; Wrong population.
Pearce EN. Hypothyroidism and dyslipidemia: Modern concepts and approaches. Current Cardiology Reports. 2004:451-6. No data by design (e.g. opinion, letter, editorial).
Pearce EN. Thyroid dysfunction in perimenopausal and postmenopausal women. Menopause Int. 2007/04/24. ed2007:8-13. No data by design (e.g. opinion, letter, editorial).
Peng L, Gu M-J. [Influence of thyroxine treatment on serum lipid levels in patients with subclinical hypothyroidism: A meta-analysis]. Academic Journal of Second Military Medical University. 2007:519-23. Related to topic but does not meet criteria for study design or quality.
Peppa M, Hadjidakis D, Alevizaki M, Dimitriadis G, Isari G, Economopoulos T, et al. Insulin Resistance and Oxidative Stress Induce Advanced Glycation End Products Formation in Patients with Clinical and Subclinical Hypothyroidism. 2008. 10th European Congress of Endocrinology (ECE 2008). Berlin (Germany). 3-7 May 2008. No relevance to key questions.
Perez A, Cubero JM, Sucunza N, Ortega E, Arcelus R, Rodriguez-Espinosa J, et al. Emerging cardiovascular risk factors in subclinical hypothyroidism: lack of change after restoration of euthyroidism. Metabolism. 2004/11/13. ed2004:1512-5. Wrong population; No relevance to key questions.
Pietras SM, Safer JD. Diagnostic confusion attributable to spurious elevation of both total thyroid hormone and thyroid hormone uptake measurements in the setting of autoantibodies: case report and review of related literature. Endocr Pract. 2008/11/11. ed2008:738-42. Related to topic but does not meet criteria for study design or quality.
Pimentel L, Hansen KN. Thyroid disease in the emergency department: A clinical and laboratory review. Journal of Emergency Medicine. 2005:201-9. No data by design (e.g. opinion, letter, editorial); No relevance to key questions.
Pingitore A, Iervasi G. Triiodothyronine (T3) effects on cardiovascular system in patients with heart failure. Recent Pat Cardiovasc Drug Discov. 2008/01/29. ed2008:19-27. No data by design (e.g. opinion, letter, editorial).
Portella RB, Da Costa, Silva JL, Wagman MB, De Oliveira FP, Buescu A, Vaisman M. Exercise performance in young and middle-aged female patients with subclinical hyperthyroidism. Thyroid. 2006:731-5. No relevance to key questions.
Prats Julia M. [Effect of treatment with levothyroxine in the lipid profile of the patients with subclinical hypothyroidism]. Endocrinol Nutr. 2009:13-7. Related to topic but does not meet criteria for study design or quality.
Premawardhana LDKE, Lazarus JH. Management of thyroid disorders. Postgraduate Medical Journal. 2006:552-8. No data by design (e.g. opinion, letter, editorial).
Rachmatullov FK, Bondarenko LA, Bibarsova AM, Kapelovich V, Osipova VV, Karakina AN, et al. [Hemodynamics, electrophysiological parameters of the heart and differential therapy of attacks of atrial fibrillation in patients with subclinical thyroid dysfunction]. Kardiologiia. 2003/08/02. ed2003:48-51. Wrong population.
Radacsi A, Kovacs G, Bernard W, Feldkamp J, Horster FA, Szabolcs I. Mortality rate of chronically ill geriatric patients with subnormal serum thyrotropin concentration: a 2-yr follow-up study. Endocrine. 2003/08/05. ed2003:133-6. No relevance to key questions; Wrong population.
Rao P, Pereira O, Weaver J. The Outcome of the Management of Subclinical Hyperthyroidism: Use of Fixed Dose of Radioiodine Therapy. 2007. BES Conference of the Society for Endocrinology. International Convention Centre, Birmingham (UK). 5-8 Mar 2007. Related to topic but does not meet criteria for study design or quality.
Rasic-Milutinovic Z, Milicevic D, Gluvic Z, Vujovic M, Tica J, Popovic-Radinovic V, et al. Subclinical Hypothyroidism and Bone Mineral Density. 2008. 10th European Congress of Endocrinology (ECE 2008). Berlin (Germany). 3-7 May 2008. No relevance to key questions.
Razvi S, McMillan CV, Weaver JU. Quality of Life, Health Status, Symptoms and Treatment Satisfaction in Subclinical Hypothyroidism: A Double–Blind 12-Week Cross–Over Study of L-Thyroxine Versus Placebo. 2006. 8th European Congress of Endocrinology (ECE 2006). SECC Congress Centre, Glasgow, Scotland (UK). 1-5 Apr 2006. Related to topic but does not meet criteria for study design or quality.
Razvi S, Pearce S, Weaver J. Does L-Thyroxine Reduce Weight in People with Subclinical Hypothyroidism?. 2006. 197th Meeting of the Society for Endocrinology. Kensington Town Hall, London (UK). 6-7 Nov 2006. Related to topic but does not meet criteria for study design or quality.
Razvi S, Weaver JU. Subclinical hypothyroidism and cardiovascular risk. Thyroid. 2004/12/14. ed2004:870. author reply 1-2. No data by design (e.g. opinion, letter, editorial).
Razvi S IL, McMillan CV, Weaver JU. Health status in patients with sub-clinical hypothyroidism. Eur J Endocrinol. May. 2005:713-7. No relevance to key questions.
Razvi Sea. Incident ischemic heart disease and thyroid status: The Whickham cohort reevaluated. Thyroid. 2007:S-72. #89. No data by design (e.g. opinion, letter, editorial) no data.
Rege V, Mojiminiyi O, Wilcox H, Barron J. Comparison of Kodak Amerlite FT4 and TSH-30 with T4 and TSH as first-line thyroid function tests. Clin Biochem. 1996/02/01. ed1996:1-4. No relevance to key questions.
Resta O, Carratu P, Carpagnano GE, Maniscalco M, Di Gioia G, Lacedonia D, et al. Influence of subclinical hypothyroidism and T4 treatment on the prevalence and severity of obstructive sleep apnoea syndrome (OSAS). J Endocrinol Invest. 2006/01/20. ed2005:893-8. Wrong population.
Reverter JL, Holgado S, Alonso N, Salinas I, Granada ML, Sanmarti A. Lack of deleterious effect on bone mineral density of long-term thyroxine suppressive therapy for differentiated thyroid carcinoma. Endocr Relat Cancer. 2005/12/03. ed2005:973-81. Wrong population.
Roberts CG, Ladenson PW. Hypothyroidism. Lancet. 2004/03/16. ed2004:793-803. Background -review.
Roti E, Gardini E, Magotti MG, Pilla S, Minelli R, Salvi M, et al. Are thyroid function tests too frequently and inappropriately requested?. J Endocrinol Invest. 1999/04/29. ed1999:184-90. Background -review.
Sait Gonen M, Kisakol G, Savas Cilli A, Dikbas O, Gungor K, Inal A, et al. Assessment of anxiety in subclinical thyroid disorders. Endocr J. 2004/07/17. ed2004:311-5. No relevance to key questions.
Sakaki T, Fujioka Y, Akagami T, Masai M, Shimizu H, Sakoda T, et al. Cardiac wall motion abnormalities observed in a patient with transient hyperthyroidism. Japanese Heart Journal. 2004:1071-7. Wrong population.
Saler T, Saglam ZA, Korkmaz K, Ataoglu HE, Yenigun M, Oguzhan B. The Effect of L-Thyroxin Theraphy on Left Ventricular Diastolic Dysfunction in Patients with Subclinical Hypothyroidism. 9th European Congress of Endocrinology (ECE 2007). Budapest (Hungary). 28 Apr-2 May 2007. No relevance to key questions.
Samuels MH. Cognitive function in untreated hypothyroidism and hyperthyroidism. Curr Opin Endocrinol Diabetes Obes. 2008/09/05. ed2008:429-33. No relevance to key questions.
Samuels MH, Schuff KG, Carlson NE, Carello P, Janowsky JS. Health status, mood, and cognition in experimentally induced subclinical hypothyroidism. J Clin Endocrinol Metab. 2007/05/03. ed2007:2545-51. Wrong population.
Santhana Krishnan SG, Pathalapati R, Kaplan L, Cobbs RK. Falsely raised TSH levels due to human anti-mouse antibody interfering with thyrotropin assay. Postgrad Med J. 2006/11/14. ed2006:e27. No relevance to key questions; No data by design (e.g. opinion, letter, editorial).
Schiff GD, Kim S, Krosnjar N, Wisniewski MF, Bult J, Fogelfeld L, et al. Missed hypothyroidism diagnosis uncovered by linking laboratory and pharmacy data. Arch Intern Med. 2005/03/16. ed2005:574-7. Wrong population.
Sengul E, Cetinarslan B, Tarkun I, Canturk Z, Turemen E. Homocysteine concentrations in subclinical hypothyroidism. Endocr Res. 2004/11/24. ed2004:351-9. No relevance to key questions.
Serter R, Demirbas B, Korukluoglu B, Culha C, Cakal E, Aral Y. The effect of L-thyroxine replacement therapy on lipid based cardiovascular risk in subclinical hypothyroidism. J Endocrinol Invest. 2005/03/15. ed2004:897-903. Related to topic but does not meet criteria for study design or quality.
Sgarbi JA, Villaca FG, Garbeline B, Villar HE, Romaldini JH. The effects of early antithyroid therapy for endogenous subclinical hyperthyroidism in clinical and heart abnormalities. J Clin Endocrinol Metab. 2003/04/08. ed2003:1672-7. No relevance to key questions.
Shinno H, Inami Y, Inagaki T, Kawamukai T, Utani E, Nakamura Y, et al. Successful treatment with levothyroxine for idiopathic hypersomnia patients with subclinical hypothyroidism. General Hospital Psychiatry. 2009:190-3. No data by design (e.g. opinion, letter, editorial).
Siegmund W, Spieker K, Weike AI, Giessmann T, Modess C, Dabers T, et al. Replacement therapy with levothyroxine plus triiodothyronine (bioavailable molar ratio 14 : 1) is not superior to thyroxine alone to improve well-being and cognitive performance in hypothyroidism. Clin Endocrinol (Oxf). 2004/05/28. ed2004:750-7. Wrong population.
Simonsick EM, Newman AB, Ferrucci L, Satterfield S, Harris TB, Rodondi N, et al. Subclinical Hypothyroidism and Functional Mobility in Older Adults. Arch Intern Med. 2009:2011-7. Background – effect of elevated TSH.
Smit JWA, Eustatia-Rutten CFA, Corssmit EPM, Pereira AM, Frolich M, Bleeker GB, et al. Reversible diastolic dysfunction after long-term exogenous subclinical hyperthyroidism: A randomized, placebo-controlled study. Journal of Clinical Endocrinology and Metabolism. 2005:6041-7. Wrong population.
Snabboon T, Sridama V, Sunthornyothin S, Suwanwalaikorn S, Vongthavaravat V. A more appropriate algorithm of thyroid function test in diagnosis of hyperthyroidism for Thai patients. J Med Assoc Thai. 2005/08/09. ed2004:S19-21. No relevance to key questions.
Spencer CA, Hollowell JG, Kazarosyan M, Braverman LE. National Health and Nutrition Examination Survey III Thyroid-Stimulating Hormone (TSH)-Thyroperoxidase Antibody Relationships Demonstrate That TSH Upper Reference Limits May Be Skewed by Occult Thyroid Dysfunction. J Clin Endocrinol Metab. 2007:4236-40. No relevance to key questions.
Squizzato A, Romualdi E, Piantanida E, Gerdes VE, Buller HR, Tanda M, et al. Subclinical hypothyroidism and deep venous thrombosis. A pilot cross-sectional study. Thromb Haemost. 2007/05/05. ed2007:803-6. No relevance to key questions.
Surks MI. Commentary: subclinical thyroid dysfunction: a joint statement on management from the American Association of Clinical Endocrinologists, the American Thyroid Association, and the Endocrine Society. J Clin Endocrinol Metab. 2005:586-7. Background -review.
Surks MI. Primary hypothyroidism: new issues and controversies. Endocrinologist. 2006:203-7. No data by design (e.g. opinion, letter, editorial).
Surks MI, Goswami G, Daniels GH. The thyrotropin reference range should remain unchanged. Journal of Clinical Endocrinology and Metabolism. 2005:5489-96. No data by design (e.g. opinion, letter, editorial).
Surks MI, Hollowell JG. Age-Specific Distribution of Serum Thyrotropin and Antithyroid Antibodies in the U.S. Population: Implications for the Prevalence of Subclinical Hypothyroidism. J Clin Endocrinol Metab. 2007:4575-82. Background – effect of elevated TSH.
Surks MI, Ortiz E, Daniels GH, Sawin CT, Col NF, Cobin RH, et al. Subclinical thyroid disease: scientific review and guidelines for diagnosis and management. Jama. 2004/01/15. ed2004:228-38. Related to topic but does not meet criteria for study design or quality.
Taddei S, Caraccio N, Virdis A, Dardano A, Versari D, Ghiadoni L, et al. Impaired Endothelium-Dependent Vasodilatation in Subclinical Hypothyroidism: Beneficial Effect of Levothyroxine Therapy. J Clin Endocrinol Metab. 2003:3731-7. Related to topic but does not meet criteria for study design or quality.
Teixeira P, Cabral MD, Silva NA, Soares DV, Braulio V, Couto AP, et al. Serum leptin in overt and subclinical hypothyroidism: effect of levothyroxine treatment and relationship to menopausal status and body composition. Thyroid. 2009:443-50. Related to topic but does not meet criteria for study design or quality.
Teixeira Pde F, Reuters VS, Ferreira MM, Almeida CP, Reis FA, Buescu A, et al. Lipid profile in different degrees of hypothyroidism and effects of levothyroxine replacement in mild thyroid failure. Transl Res. 2008/03/22. ed2008:224-31. Wrong population.
Teixeira PF, Reuters VS, Ferreira MM, Almeida CP, Reis FA, Melo BA, et al. Treatment of subclinical hypothyroidism reduces atherogenic lipid levels in a placebo-controlled double-blind clinical trial. Horm Metab Res. 2007/12/19. ed2008:50-5. Wrong population.
Trokoudes KM, Skordis N, Picolos MK. Infertility and thyroid disorders. Curr Opin Obstet Gynecol. 2006/06/24. ed2006:446-51. No data by design (e.g. opinion, letter, editorial).
Turhan S, Tulunay C, Ozduman Cin M, Gursoy A, Kilickap M, Dincer I, et al. Effects of thyroxine therapy on right ventricular systolic and diastolic function in patients with subclinical hypothyroidism: a study by pulsed wave tissue Doppler imaging. J Clin Endocrinol Metab. 2006/07/11. ed2006:3490-3. Wrong population; No relevance to key questions.
Unal O, Erturk E, Ozkan H, Kiyici S, Guclu M, Ersoy C, et al. Effect of levothyroxine treatment on QT dispersion in patients with subclinical hypothyroidism. Endocr Pract. 2008/01/16. ed2007:711-5. Related to topic but does not meet criteria for study design or quality.
Vaidya B, Williams GR, Abraham P, Pearce SH. Radioiodine treatment for benign thyroid disorders: results of a nationwide survey of UK endocrinologists. Clin Endocrinol (Oxf). 2007/11/02. ed2008:814-20. No relevance to key questions.
Vaisman M, Teixeira P, Martins J, Soares D, Braulio V, Buescu A, et al. Effects of Levothyroxine Reposition on Insulin Sensitivity, Leptin Levels and Fat Mass in Patients with Subclinical Hypothyroidism. 32nd Annual Meeting of the European Thyroid Association. Carl Ludwig Institute, University Hospital Leipzig, Leipzig (Germany). 1-5 Sep 2007. 2007:75. Related to topic but does not meet criteria for study design or quality.
van den Beld AW, Visser TJ, Feelders RA, Grobbee DE, Lamberts SWJ. Thyroid Hormone Concentrations, Disease, Physical Function, and Mortality in Elderly Men. J Clin Endocrinol Metab. 2005:6403-9. No relevance to key questions.
Vanderpump M. Subclinical hypothyroidism: the case against treatment. Trends Endocrinol Metab. 2003/08/02. ed2003:262-6. Background -review.
van Harten AC, Leue C, Verhey FR. [Should depressive symptoms in patients with subclinical hypothyroidism be treated with thyroid hormone?]. Tijdschr Psychiatr. 2008/08/09. ed2008:539-43. Related to topic but does not meet criteria for study design or quality.
Velija-Asimi Z, Heljic B. Changes in Cystatin C during the Treatment of Subclinical Hypothyroidism. 2008. 10th European Congress of Endocrinology (ECE 2008). Berlin (Germany). 3-7 May 2008. No relevance to key questions.
Velija-Asimi Z, Karamehic J. The effects of treatment of subclinical hypothyroidism on metabolic control and hyperinsulinemia. Med Arh. 2007/06/23. ed2007:20-1. Related to topic but does not meet criteria for study design or quality.
Vergara P, Picardi G, Nigro G, Scaturo F, de Chiara A, CalabrÃ² R, et al. Evaluation of thyroid dysfunction in patients with paroxysmal atrial fibrillation. Anadolu Kardiyoloji Dergisi. 2007:104-6. No relevance to key questions.
Villar H, Gharib H. Review: Available evidence does not support a benefit for thyroid hormone replacement in adults with subclinical hypothyroidism: Commentary. Evidence-Based Medicine. 2008:22. %N 1. No data by design (e.g. opinion, letter, editorial.
Villar HC, Saconato H, Valente O, Atallah AN. Thyroid hormone replacement for subclinical hypothyroidism. Cochrane Database Syst Rev. 2007/07/20. ed2007:CD003419. Related to topic but does not meet criteria for study design or quality.
Volzke H, Dorr M, Wallaschofski H. Is Subclinical Hyperthyroidism Associated with Blood Pressure and Hypertension?. 2006. 8th European Congress of Endocrinology (ECE 2006). SECC Congress Centre, Glasgow, Scotland (UK). 1-5 Apr 2006. No relevance to key questions.
Volzke H, Schwahn C, Wallaschofski H, Dorr M. Review: The association of thyroid dysfunction with all-cause and circulatory mortality: is there a causal relationship?. J Clin Endocrinol Metab. 2007/05/03. ed2007:2421-9. No data by design (e.g. opinion, letter, editorial).
Waise A, Price HC. The upper limit of the reference range for thyroid-stimulating hormone should not be confused with a cut-off to define subclinical hypothyroidism. Ann Clin Biochem. 2009/01/24. ed2009:93-8. Background – effect of elevated TSH.
Walsh JP, Bremner AP, Bulsara MK, O'Leary P, Leedman PJ, Feddema P, et al. Subclinical thyroid dysfunction and blood pressure: a community-based study. Clin Endocrinol (Oxf). 2006/09/21. ed2006:486-91. No data by design (e.g. opinion, letter, editorial).
Wartofsky L, Dickey RA. The evidence for a narrower thyrotropin reference range Is compelling. J Clin Endocrinol Metab. 2005:5483-8. No data by design (e.g. opinion, letter, editorial).
Wartofsky L, Van Nostrand D, Burman KD. Overt and 'subclinical' hypothyroidism in women. Obstet Gynecol Surv. 2006/07/18. ed2006:535-42. No data by design (e.g. opinion, letter, editorial).
Weetman AP. Radioiodine treatment for benign thyroid diseases. Clin Endocrinol (Oxf). 2007/05/01. ed2007:757-64. No relevance to key questions.
Weise AM, Liu CY, Shields AF. Fatal liver failure in a patient on acetaminophen treated with sunitinib malate and levothyroxine. Annals of Pharmacotherapy. 2009:761-6. Wrong population.
Weissel M. Disturbances of thyroid function in the elderly. Wien Klin Wochenschr. 2006/02/21. ed2006:16-20. No data by design (e.g. opinion, letter, editorial).
Wilson GR, Curry RW Jr. Subclinical thyroid disease. Am Fam Physician. 2005/11/09. ed2005:1517-24. No data by design (e.g. opinion, letter, editorial).
Woeber K. Observations concerning the natural history of subclinical hyperthyroidism. Thyroid. 2005:687. No relevance to key questions.
Yandell SD, Harvey WC, Fernandes NJ, Barr PW, Feldman M. Radioiodine studies, low serum thyrotropin, and the influence of statin drugs. Thyroid. 2008/09/20. ed2008:1039-42. No relevance to key questions.
Yavuz DG, Yazici D, Toprak A, Deyneli O, Aydin H, Yuksel M, et al. Exogenous subclinical hyperthyroidism impairs endothelial function in nodular goiter patients. Thyroid. 2008/04/11. ed2008:395-400. Wrong population.
Yavuz DG, Yuksel M, Deyneli O, Ozen Y, Aydin H, Akalin S. Association of serum paraoxonase activity with insulin sensitivity and oxidative stress in hyperthyroid and TSH-suppressed nodular goitre patients. Clin Endocrinol (Oxf). 2004;61(4):515-21. Octinitial search 6/11/2009. No relevance to key questions. [pmid: 15473886].
Yazici M, Gorgulu S, Sertbas Y, Erbilen E, Albayrak S, Yildiz O, et al. Effects of thyroxin therapy on cardiac function in patients with subclinical hypothyroidism: index of myocardial performance in the evaluation of left ventricular function. Int J Cardiol. 2004/06/15. ed2004:135-43. Wrong population.
Zargar AH, Ganie MA, Masoodi SR, Laway BA, Bashir MI, Wani AI, et al. Prevalence and pattern of sick euthyroid syndrome in acute and chronic non-thyroidal illness-its relationship with severity and outcome of the disorder. The Journal of the Association of Physicians of India. 2004:27-31. No relevance to key questions.
Zhu D-F, Wang Z-X, Zhang D-R, Pan Z-L, He S, Hu X-P, et al. fMRI revealed neural substrate for reversible working memory dysfunction in subclinical hypothyroidism. Brain. 2006:2923-30. Related to topic but does not meet criteria for study design or quality.
Zwirska-Korczala K, Berdowska A, Jochem J, Sitkiewicz A, Birkner E, Polaniak R, et al. Influence of thyroxine on serum soluble interleukin-2 receptor alpha levels in thyroid disorders. J Clin Pharm Ther. 2004/04/08. ed2004:151-6. Wrong population.