# Search Strategies

## Search Strategy for Systematic Reviews and Observational Studies

| Set # | Concept | Search strategy
MEDLINE (PubMed) 3/3/10 | #1 | Sub-clinical Thyroid Disease | ( Hyperthyroidism [Mesh] OR Hypothyroidism [Mesh]OR (hypothyr* OR hypo-thyr* OR hyperthyr* OR hyper-thyr*) [tiab] OR (thyroid deficien* OR thyroid insufficien* OR thyroid failure) [tiab]) AND ( (mild OR compens* OR subclinic* OR moderat* OR short-term) [tiab]) OR elevated tsh [tiab])
MEDLINE (PubMed) 3/3/10 | #2 | Screening | Mass Screening [mesh]OR Thyroid Function Tests [mesh]OR (screening OR casefinding OR case finding) [tiab]
MEDLINE (PubMed) 3/3/10 | #3 | Treatment for hyperthyroidism | anti-thyroid [tiab]OR methimazole [tiab]OR Methimazole [mesh]OR propylthiouracil [tiab]OR Propylthiouracil [mesh]OR (radioactive [tiab] OR radioiodine [tiab])
MEDLINE (PubMed) 3/3/10 | #4 | Treatment for hypothyroidism | T3 [tiab] OR T4 [tiab] OR thyroxine [tiab] OR thyroxine [mesh] OR levothyroxine [tiab] OR triiodothyronine [tiab] OR triiodothyronine[mesh]OR liothyronine [tiab] OR (thyrolar [tiab] OR liotrix [tiab]) AND (therapeutic use [sh] OR treatment [tiab] OR therapy [tiab])
MEDLINE (PubMed) 3/3/10 | #5 | Screening or treatment of sub-clinical thyroid disease | #1 AND (#2 OR #3 OR #4)
MEDLINE (PubMed) 3/3/10 | #6 | Systematic reviews | systematic[sb]
MEDLINE (PubMed) 3/3/10 | #7 | Observational Studies | ((((((((cohort studies[MeSH Terms]) OR comparative study[MeSH Terms]) OR follow-up studies[MeSH Terms]) OR prospective studies[MeSH Terms]) OR risk factors[MeSH Terms]) OR cohort[Title/Abstract]) OR compared[Title/Abstract]) OR groups[Title/Abstract]) OR multivariate[Title/Abstract]
MEDLINE (PubMed) 3/3/10 | | Systematic Reviews of screening or treatment for subclinical thyroid disease | #6 AND #5 N=39
MEDLINE (PubMed) 3/3/10 | | Observational Studies of Screening for subclinical thyroid disease | #1 AND #2 AND #7 limited to year 2002 and beyond N=236
MEDLINE (PubMed) 3/3/10 | | | [MeSH] = exploded term, all subterms and subtrees included [tiab] = in title and abstract * = truncation
Cochrane Register Database of Systematic Reviews and Database of Abstracts of Reviews of Effects (OVID) 3/3/2010 | #1 | Sub-clinical Thyroid Disease | ((hyperthyroidism.mp. OR hypothyroidism.mp. OR (hypothryr* or hypo-thyr* or hyperthryr* or hyper-thyr*).mp. OR (thyroid deficien* or thryroid insufficien* or thryroid failure).mp.) AND ((mild or compens* or subclinic* or moderat* or short-term).mp.)) OR elevated adj3 tsh.mp.
Cochrane Register Database of Systematic Reviews and Database of Abstracts of Reviews of Effects (OVID) 3/3/2010 | #2 | Screening | mass screening.mp. or OR thyroid function tests.mp. or OR screening.mp. OR casefinding.mp OR case finding.mp.
Cochrane Register Database of Systematic Reviews and Database of Abstracts of Reviews of Effects (OVID) 3/3/2010 | #3 | Treatment for hyperthyroidism | Antithyroid Agents.mp. OR anti-thyroid.mp. OR methimazole.mp. OR propylthiouracil.mp. OR radioiodine.mp. or radioactive.mp.
Cochrane Register Database of Systematic Reviews and Database of Abstracts of Reviews of Effects (OVID) 3/3/2010 | #4 | Treatment for hypothyroidism | t3.mp. OR t4.mp. OR thyroxine.mp. OR levothyroxine.mp. OR triiodothyronine.mp. OR liothyronine.mp. OR thyrolar.mp. or liotrix.mp.
Cochrane Register Database of Systematic Reviews and Database of Abstracts of Reviews of Effects (OVID) 3/3/2010 | | Systematic Reviews of screening or treatment for subclinical thyroid disease | #1 AND (#2 OR #3 OR #4) N=40 after deduplication 35

## Search Strategy for Individual Studies

| Set# | Concept | Search strategy
MEDLINE (PubMed) | #1 | Sub-clinical Thyroid Disease | ( Hyperthyroidism [mesh] OR Hypothyroidism [mesh](hypothyr* OR hypo-thyr* OR hyperthyr* OR hyper­thyr*) [tiab] OR (thyroid deficien* OR thyroid insufficien* OR thyroid failure) [tiab]) AND ( (mild OR compens* OR subclinic* OR moderat* OR short-term) [tiab]) OR elevated tsh [tiab]
MEDLINE (PubMed) | #2 | Screening | Mass Screening [mesh]OR Thyroid Function Tests [mesh]OR (screening OR casefinding OR case finding) [tiab]
MEDLINE (PubMed) | #3 | Treatment for hyperthyroidism | anti-thyroid [tiab]OR methimazole [tiab]OR Methimazole [mesh]OR propylthiouracil [tiab]OR Propylthiouracil [mesh]OR (radioactive [tiab] OR radioiodine [tiab])
MEDLINE (PubMed) | #4 | Treatment for hypothyroidism | T3 [tiab] OR T4 [tiab] OR thyroxine [tiab] OR thyroxine [mesh] OR levothyroxine [tiab] OR triiodothyronine [tiab] OR triiodothyronine[mesh]OR liothyronine [tiab] OR (thyrolar [tiab] OR liotrix [tiab]) AND (therapeutic use [sh] OR treatment [tiab] OR therapy [tiab])
MEDLINE (PubMed) | #5 | Treatment in general | ((clinical[Title/Abstract] AND trial[Title/Abstract]) OR clinical trials[MeSH Terms] OR clinical trial[Publication Type] OR random*[Title/Abstract] OR random allocation[MeSH Terms] OR therapeutic use[MeSH Subheading])
MEDLINE (PubMed) | #6 | Harms | (adverse effects [sh] OR poisoning [sh]OR toxicity [sh]OR contraindications [sh]OR complications [sh]) OR ( (safe OR safety OR side-effect$ OR undesirable effect$ OR treatment emergent OR tolerability OR toxicity) [tw]) OR ( adverse [tiab] AND (effect$ OR reaction$ OR event$ OR outcome$) [tiab])
MEDLINE (PubMed) | #7 | Patient issues of testing | Patient Satisfaction[Mesh]OR Perception[Mesh] OR Family[Mesh] OR Stress, Physiological[Mesh] OR Attitude to Health[Mesh]OR False Positive Reactions [Mesh] OR patient preference* [tiab] OR consequence* [tiab]OR cost [tiab] OR costs [tiab] OR false positive* [tiab]OR acceptability [tiab] OR worry [tiab]
MEDLINE (PubMed) | #8 | RCTs | (randomized controlled trial [pt] OR controlled clinical trial [pt] OR randomized [tiab] OR placebo [tiab] OR clinical trials as topic [mesh: noexp] OR randomly [tiab] OR trial [ti]) NOT (animals [MeSH] not (humans [MeSH] and animals [MeSH]))
MEDLINE (PubMed) | | KQ1 Screening for Subclinical Thyroid Disease | #1 AND #2 AND #8
MEDLINE (PubMed) | | KQ2 Harms of Screening | (#6 OR #7) AND (#1 AND #2)
MEDLINE (PubMed) | | KQ3a treatment hyper | #1 AND #3 AND #5
MEDLINE (PubMed) | | KQ3b treatment hypo | #1 AND #4 AND #8
MEDLINE (PubMed) | | KQ4 harms of treatment | (#3 OR #4) AND #6 AND #1
MEDLINE (PubMed) | | | [MeSH] = exploded term, all subterms and subtrees included [mesh: noexp] = non-exploded term, no subterms or subtrees included [tiab] = in title and abstract [tw] = word anywhere in the record [pt] = publication type * = truncation all searches were limited to publication date 2002 or later
Cochrane Register of Controlled Trials (OVID) | #1 | Sub-clinical Thyroid Disease | ((hyperthyroidism.mp. or exp Hyperthyroidism/ OR exp Hypothyroidism/ or hypothyroidism.mp. OR (hypothryr* or hypo-thyr* or hyperthryr* or hyper-thyr*).mp. OR (thyroid deficien* or thryroid insufficien* or thryroid failure).mp.) AND ((mild or compens* or subclinic* or moderat* or short-term).mp.)) OR elevated adj3 tsh.mp.
Cochrane Register of Controlled Trials (OVID) | #2 | Screening | mass screening.mp. or exp Mass Screening/ OR thyroid function tests.mp. or exp Thyroid Function Tests/ OR screening.mp. OR casefinding.mp OR case finding.mp.
Cochrane Register of Controlled Trials (OVID) | #3 | Treatment for hyperthyroidism | exp Antithyroid Agents/ or anti-thyroid.mp. OR methimazole.mp. or exp Methimazole/ OR propylthiouracil.mp. or exp Propylthiouracil/ OR radioiodine.mp. or radioactive.mp.
Cochrane Register of Controlled Trials (OVID) | #4 | Treatment for hypothyroidism | t3.mp. OR t4.mp. OR exp Thyroxine/ or thyroxine.mp. OR levothyroxine.mp. OR exp Triiodothyronine/ or triiodothyronine.mp. OR liothyronine.mp. OR thyrolar.mp. or liotrix.mp.
Cochrane Register of Controlled Trials (OVID) | | KQ1/2 Screening | #1 AND #2
Cochrane Register of Controlled Trials (OVID) | | KQ3/4 Treatment | #2 AND (#3 OR #4)
Cochrane Register of Controlled Trials (OVID) | | | all searches limited to publication date 2002 to current
AGELINE (AARP.org) | | | hyperthyroidism ; hypothyroidism ; "thyroid deficien*" ; "thyroid insufficien*" ; "thyroid failure" AND “mild; compens* ; subclinic* ; moderat* ; “short-term” [ all content any position ; = OR]
EMBASE (EMBASE.com) | | Screening Search (KQ1 and KQ2) | (('hyperthyroidism'/syn OR 'hypothyroidism'/syn OR 'thyroid deficien' OR 'thyroid insufficien' OR 'thyroid failure') AND (mild OR compens* OR subclinic* OR moderat* OR 'short-term') OR 'elevated tsh') AND ('mass screening' OR 'thyroid function tests' OR screening OR casefinding OR case AND finding)
EMBASE (EMBASE.com) | | Treatment KQ3 and KQ4 | ((('hyperthyroidism'/syn OR 'hypothyroidism'/syn OR 'thyroid deficien' OR 'thyroid insufficien' OR 'thyroid failure') AND (mild OR compens* OR subclinic* OR moderat* OR 'short-term') OR 'elevated tsh') AND (('t3'/exp OR t4 OR 'thyroxine'/exp OR 'levothyroxine'/exp OR 'triiodothyronine'/exp OR 'liothyronine'/exp) AND ('therapeutic use' OR treatment OR 'therapy'/exp) OR ('anti thyroid' OR ('methimazole'/exp OR 'methimazole') OR propythiouracil)) AND (random OR ('placebo'/exp OR 'placebo') OR 'double blind')
EMBASE (EMBASE.com) | | Harms of Treatment KQ4 | ((('hyperthyroidism'/syn OR 'hypothyroidism'/syn OR 'thyroid deficien' OR 'thyroid insufficien' OR 'thyroid failure') AND (mild OR compens* OR subclinic* OR moderat* OR 'short-term') OR 'elevated tsh') AND (('t3'/exp OR t4 OR 'thyroxine'/exp OR 'levothyroxine'/exp OR 'triiodothyronine'/exp OR 'liothyronine'/exp) AND ('therapeutic use' OR treatment OR 'therapy'/exp) OR ('anti thyroid' OR ('methimazole'/exp OR 'methimazole') OR propythiouracil)) AND (('adverse effects' OR ('poisoning'/exp OR 'poisoning') OR ('toxicity'/exp OR 'toxicity') OR contraindications OR complications OR safe OR ('safety'/exp OR 'safety') OR 'side effect'$ OR undesirable AND effect$ OR treatment AND emergent OR tolerability OR ('toxicity'/exp OR 'toxicity')) OR (adverse AND (effect$ OR reaction$ OR event$ OR outcome$)))
Grey Literature | | Type of information | Sources Searched
Grey Literature | | Clinical Trials | ClinicalTrials.gov Current Controlled Trials Clinical Study Results WHO Clinical Trials
Grey Literature | | Regulatory Information | FDA Health Canada Authorized Medicines for EU
Grey Literature | | Conference Proceedings | Conference Papers Index Scopus
Grey Literature | | Other | NIH RePORTER (a searchable database of federally funded biomedical research projects conducted at universities, hospitals, and other research institutions) HSRPROJ (a database providing access to ongoing grants and contracts in health services research) Hayes, Inc. Health Technology Assessment NY Academy of Medicine’s Grey Literature Index

## Foreign Language Search Strategy

| Set# | Concept | Search strategy
CINAHL (EBSCO) 1­15-2010 | #1 S17 N=266 | Sub-clinical Thyroid Disease | (((MH "Hyperthyroidism+") OR (MH "Hypothyroidism+") OR (ti hypothyr* OR ti hypo-thyr* OR ti hyperthyr* OR ti hyper­thyr* OR ab hypothyr* OR ab hypo-thyr* OR ab hyperthyr* OR ab hyper-thyr* OR ti thyroid deficien* OR ti thyroid insufficien* OR ti thyroid failure OR ti thyroid deficien* OR ti thyroid insufficien* OR ti thyroid failure) ) AND (ti mild OR ti compens* OR ti subclinic* OR ti moderat* OR ti short-term OR ab mild OR ab compens* OR ab subclinic* OR ab moderat* OR ab short-term )) OR (ti elevated tsh OR ab elevated tsh)
CINAHL (EBSCO) 1­15-2010 | #2 S22 N=53698 | Screening | (MH "Health Screening+") OR (MH "Thyroid Function Tests+") OR (ti screening OR ti casefinding OR ti case finding) OR (ab screening OR ab casefinding OR ab case finding )
CINAHL (EBSCO) 1­15-2010 | #3 S28 N=382 | Treatment for hyperthyroidism | radioiodine OR ti radioactive OR ("anti-thyroid") or (MH "Thyroid Antagonists") OR propythiouracil OR methimazole
CINAHL (EBSCO) 1­15-2010 | #4 S41 N=1082 | Treatment for hypothyroidism | (liotrix OR thyrolar OR liothyronine OR triiodothyronine OR "levothyroxine" OR ("thyroxine") OR (MH "Thyroxine") OR ti t4 OR ab t4 OR ti T3 OR ab T3) AND (ti treatment OR ab treatment OR ti therapy OR ab therapy OR ("therapeutic use") or (MH "Therapeutics"))
CINAHL (EBSCO) 1­15-2010 | #5 S48 N=647228 | Treatment in general | (MH "Therapeutics+") OR (MH "Random Assignment") OR ti random* OR ab random* OR pt clinical trial OR (MH "Clinical Trials+") OR (ti clinical OR ab clinical) AND (ti trial OR ab trial)
CINAHL (EBSCO) 1­15-2010 | #6 S55 N=372918 | Harms | ("adverse effects") OR (MH "Adverse Drug Event") OR (MH "Adverse Health Care Event") OR ("poisoning") or (MH "Poisoning") OR ("toxicity") or (MH "Drug Toxicity") OR "contraindications" OR ("complications") or (MH "Treatment Complications, Delayed") OR ("safety") OR (MH "Safety")
CINAHL (EBSCO) 1­15-2010 | #7 S63 N=149782 | Patient issues of testing | patient preference* OR consequence* OR cost OR costs OR false positive* OR acceptability OR worry OR (MH "False Positive Results") OR (MH "False Negative Results") OR (MH "Attitude to Health") OR (MH "Stress") OR (MH "Family") OR (MH "Perception") OR (MH "Patient Satisfaction")
CINAHL (EBSCO) 1­15-2010 | #8 S68 N=80675 | RCTs | (MH "Clinical Trials") OR ti randomized OR ti placebo OR ti randomly
CINAHL (EBSCO) 1­15-2010 | | KQ1 Screening for Subclinical Thyroid Disease | #1 AND #2 AND #8 (2 results both in English)
CINAHL (EBSCO) 1­15-2010 | | KQ2 Harms of Screening | (#6 OR #7) AND (#1 AND #2) (42 results, 2 non-English)
CINAHL (EBSCO) 1­15-2010 | | KQ3a treatment hyper | #1 AND #3 AND #5 (4 results all in English)
CINAHL (EBSCO) 1­15-2010 | | KQ3b treatment hypo | #1 AND #4 AND #8 (10 results, 1 non-English)
CINAHL (EBSCO) 1­15-2010 | | KQ4 harms of treatment | (#3 OR #4) AND #6 AND #1 (40 results, 2 non-English, one of these is duplicate)
CINAHL (EBSCO) 1­15-2010 | | | 4 non-English articles found

1/15/2010

WHO Global Health Library (includes African Index Medicus, Index Medicus for the Eastern Mediterranean Region, Latin American and Caribbean Health Sciences Literature, Pan American Health Organization database, WHO Library Database, WHO Western Pacific Region database)

SEARCH: (Hyperthyroidism OR hypothyroidism) AND subclinical AND YEAR>= 2002 AND non-English language