# Lipid Conversion Factors

## To Convert From mmol/L to mg/dL

For total, HDL, and LDL cholesterol multiply mmol/L by 38.67

e.g. 3.5 mmol/L = 3.5 mmol/L * 38.67 = 135 mg/dL

For triglycerides multiply mmol/L by 88.57

e.g. 1.9 mmol/L = 1.9 mmol/L * 88.57 = 168 mg/dL

## To Convert From mg/dL

For total, HDL, and LDL cholesterol divide mg/dL by 38.67

e.g. 135 mg/dL = 135 mg/dL/38.67 = 3.5 mmol/L

For triglycerides divide mg/dL by 88.57

e.g. 168 mg/dL = 168 mg/dL/88.57 = 1.9 mmol/L