# Appendixes

Appendix A Lipid Conversion Factors

Appendix B Search Strategies

Appendix C Criteria for Assessing Internal Validity of Individual Studies

Appendix D Excluded Studies

Appendix E Screening and Case-Finding Recommendations of Other Groups

Appendix F Results of Search for Systematic Reviews