# Acknowledgments

We would like to thank Kim Marie Wittenberg, M.A., Christine Chang, M.D., Mary Barton, M.D., and David Hickam, M.D., for their helpful comments on early versions of this report, and Sasha Walia for administrative support of the project.