# Abbreviations

ACOG: The American College of Obstetricians and Gynecologists
ACP: The American College of Physicians
AHRQ: Agency for Healthcare Research and Quality
AMSTAR: Assessment of Multiple Systematic Reviews
BMI: Body Mass Index
CI: Confidence Interval
EHCP: Effective Health Care Program
EPC: Evidence-based Practice Center
HDL: High-density Lipoprotein
kg/m^2^: kilograms per meter squared (a measure of body mass index)
KQ: Key question
LDL: Low-density Lipoprotein
mcg: microgram
mg/dL: milligrams per deciliter
mIU/L: milli-international units per liter
mIU/L^2^: milli-international units per liter squared
mmHg: millimeters of mercury
ng/dl: nanograms per deciliter
PICOTS: Population, Intervention, Comparators, Outcome, Timing and Setting
RCT: Randomized Controlled Trial
SIP: Scientific Information Packet
TPO: Thyroid Peroxidase
TSH: Thyroid Stimulating Hormone
T3: Triiodothyronine
T4: Thyroxine
USPSTF: United States Preventive Services Task Force
WHO: World Health Organization