# Technical Expert Panel

Dana S. Hardin, M.D.

The Research Institute at Nationwide Children’s Hospital

Columbus, OH

Nancy R. Rodriguez, Ph.D., R.D., C.S.S.D.

University of Connecticut

Storrs, CT

Craig D. Lapin, M.D.

Connecticut Children’s Medical Center

Hartford, CT

Jeffrey Casberg, M.S., R.Ph.

ConnectiCare, Inc & Affiliates

Farmington, CT