# References

1 Centers for disease control and prevention. newborn screening for cystic fibrosis. morbidity and mortality weekly report. 2004;353(RR13):1-36.
2 Cystic Fibrosis Foundation Patient Registry. Annual Data Report. 2008.
3 Centers for disease control and prevention. national office of public health genomics. cystic fibrosis clinical validity. 2007.
4 Schnabel D, Grasemann C, Staab D, et al. German Cystic Fibrosis Growth Hormone Study, Group. A multicenter, randomized, double-blind, placebo-controlled trial to evaluate the metabolic and respiratory effects of growth hormone in children with cystic fibrosis. Pediatrics. 2007;119(6):e1230-e1238. [pmid: 17545356].
5 Hardin DS. GH improves growth and clinical status in children with cystic fibrosis—a review of published studies. Eur J Endocrinol. 2004;151(Suppl 1):S81-S85. [pmid: 15339250].
6 Sims EJ, Mugford M, Clark A, et al. Economic implications of newborn screening for cystic fibrosis: a cost of illness retrospective cohort study. Lancet. 2007;369(9568):1187-1195. [pmid: 17416263].
7 Konstan MW, Butler SM, Wohl ME, et al. Growth and nutritional indexes in early life predict pulmonary function in cystic fibrosis. J Pediatr. 2003;142(6):624-630. [pmid: 12838189].
8 Beker LT, Russek-Cohen E, Fink RJ. Stature as a prognostic factor in cystic fibrosis survival. J Am Diet Assoc. 2001;101(4):438-442. [pmid: 11320950].
9 Colombo C, Battezzati A. Growth failure in cystic fibrosis: a true need for anabolic agents? [comment]. J Pediatr. 2005;146(3):303-305. [pmid: 15756206].
10 Ramsey BW, Farrell PM, Pencharz P. Nutritional assessment and management in cystic fibrosis: a consensus report. The Consensus Committee. Am J Clin Nutr. 1992;55(1):108-116. [pmid: 1728810].
11 Stallings VA, Stark LJ, Robinson KA, et al. Clinical Practice Guidelines on Growth and Nutrition Subcommittee. Evidence-based practice recommendations for nutrition-related management of children and adults with cystic fibrosis and pancreatic insufficiency: results of a systematic review. J Am Diet Assoc. 2008;108:832-839. [pmid: 18442507].
12 Lee M, editor. Interpreting Laboratory Data. 8. Bethesda. American Society of Health-System Pharmacist. 2004.
13 Patel L, Dixon M, David TJ. Growth and growth charts in cystic fibrosis. J R Soc Med. 2003;96(Suppl 43):35-41. [pmid: 12906324].
14 Lai HC, Kosorok MR, Sondel SA, et al. Growth status in children with cystic fibrosis based on the National Cystic Fibrosis Patient Registry data: evaluation of various criteria used to identify malnutrition. J Pediatr. 1998;132(3 Pt 1):478-485. [pmid: 9544905].
15 Hardin DS, Kemp SF, Allen DB. Twenty years of recombinant human growth hormone in children: relevance to pediatric care providers. Clin Pediatr (Phila). 2007;46(4):279-286. [pmid: 17475983].
16 Hardin DS, Adams-Huet B, Brown D, et al. Growth hormone treatment improves growth and clinical status in prepubertal children with cystic fibrosis: results of a multicenter randomized controlled trial. J Clin Endocrinol Metab. 2006;91(12):4925-4929. [pmid: 17018651].
17 Drug Topics Red Book. 112. Montvale, NJ. Thomson. 2008.
18 Higgins JPT, Green S. Cochrane Database of Systematic Reviews of Interventions Version 5.0.0 [updated February 2008]. The Cochrane Collaboration. 2008.
19 WHO AnthroPlus for personal computers Manual: Software for assessing growth of the world’s children and adolescents. Geneva. WHO. 2009. Available at http://www.who.int/growthref/tools/en/.
20 NHANES united states growth charts. 2000.
21 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-188. [pmid: 3802833].
22 Follmann D, Elliott P, Suh I, et al. Variance imputation for overviews of clinical trials with continuous response. J Clin Epidemiol. 1992;45(7):769-773. [pmid: 1619456].
23 Schunermann H, Brozek J, Oxman A, editors. GRADE handbook for grading quality of evidence and strength of recommendation. The GRADE Working Group. 2008.
24 Hardin DS, Ellis KJ, Dyson M, et al. Growth hormone improves clinical status in prepubertal children with cystic fibrosis: results of a randomized controlled trial. J Pediatr. 2001;139(5):636-642. [pmid: 11713439].
25 Hardin DS, Ellis KJ, Dyson M, et al. Growth hormone decreases protein catabolism in children with cystic fibrosis. J Clin Endocrinol Metab. 2001;86(9):4424-4428. [pmid: 11549686].
26 Hutler M, Schnabel D, Staab D, et al. Effect of growth hormone on exercise tolerance in children with cystic fibrosis. Med Sci Sports Exerc. 2002;34(4):567-572. [pmid: 11932561].
27 Schibler A, von der Heiden R, Birrer P, et al. Prospective randomised treatment with recombinant human growth hormone in cystic fibrosis. Arch Dis Child. 2003;88(12):1078-1081. [pmid: 14670773].
28 von der Heiden R, Balestra AP, Bianchetti MG, et al. Which factors account for renal stone formation in cystic fibrosis?. Clin Nephrol. 2003;59(3):160-163. [pmid: 12653257].
29 von der Heiden R, Kraemer R, Birrer P, et al. Effect of growth hormone (r-hGH) treatment on working capacity, body composition, lung function and immunological parameters in patients with cystic fibrosis (CF) [abstract].
30 Darmaun D, Hayes V, Schaeffer D, et al. Effects of glutamine and recombinant human growth hormone on protein metabolism in prepubertal children with cystic fibrosis. J Clin Endocrinol Metab. 2004;89(3):1146-1152. [pmid: 15001600].
31 Hayes V, Schaeffer D, Mauras N, et al. Can glutamine and growth hormone promote protein anabolism in children with cystic fibrosis?. Horm Res. 2002;58(Suppl 1):21-23. [pmid: 12373009].
32 Schaeffer D, Darmaun D, Punati J, et al. Use of glutamine and recombinant human growth hormone (RHGH) in children with cystic fibrosis [abstract]. Pediatr Pulmonol. 2000;(Suppl 20):323.
33 Hardin DS, Ahn C, Prestidge C, et al. Growth hormone improves bone mineral content in children with cystic fibrosis. J Pediatr Endocrin Metab. 2005;18:589-595.
34 Hardin DS, Ferkol T, Ahn C, et al. A retrospective study of growth hormone use in adolescents with cystic fibrosis. Clin Endocrinol (Oxford). 2005;62(5):560-566.
35 Hardin DS, Rice J, Ahn C, et al. Growth hormone treatment enhances nutrition and growth in children with cystic fibrosis receiving enteral nutrition. J Pediatr. 2005;146(3):324-328. [pmid: 15756212].
36 Grasemann C, Ratjen F, Schnabel D, et al. Effect of growth hormone therapy on nitric oxide formation in cystic fibrosis patients. Eur Respir J. 2008;31(4):815-821. [pmid: 18094013].
37 Grasemann H, Grasemann C, Schnabel D, et al. Recombinant human growth hormone therapy results in increased systemic nitric oxide (NO) formation but decreased exhaled NO in patients with cystic fibrosis [abstract].
38 Vanderwel M, Hardin DS. Growth hormone normalizes pubertal onset in children with cystic fibrosis. J Pediatr Endocrinol. 2006;19(3):237-244.
39 Stalvey MS, Geller DE, Anbar RD, et al. Growth hormone (GH) increases height, weight and lean body mass (LBM) in prepubertal children with cystic fibrosis (CF): results of a multicenter randomized control trial. North American Cystic Fibrosis Conference. 2008;(Suppl):393.
40 Mullis PE, Liechti-Gallati S, Di Silvio L, et al. Short stature in a patient with cystic fibrosis caused by a 6.7-kb human growth hormone gene deletion. Horm Res. 1991;36(1-2):4-8. [pmid: 1687684].
41 Sackey AH, Taylor CJ, Barraclough M, et al. Growth hormone as a nutritional adjunct in cystic fibrosis: results of a pilot study. J Human Nutr and Diet. 1995;8:185-191.
42 Huseman CA, Colombo JL, Brooks MA, et al. Anabolic effect of biosynthetic growth hormone in cystic fibrosis patients. Pediatr Pulmonol. 1996;22(2):90-95. [pmid: 8875581].
43 Hardin DS, Sy JP. Effects of growth hormone treatment in children with cystic fibrosis: the National Cooperative Growth Study experience. J Pediatr. 1997;131(1 Pt 2):S65-S69. [pmid: 9255232].
44 Alemzadeh R, Upchurch L, McCarthy V. Anabolic effects of growth hormone treatment in young children with cystic fibrosis. J Am Coll Nutr. 1998;17(5):419-424. [pmid: 9791837].
45 Hardin DS, Stratton R, Kramer JC, et al. Growth hormone improves weight velocity and height velocity in prepubertal children with cystic fibrosis. Horm Metab Res. 1998;30(10):636-641. [pmid: 9851673].
46 Petrowsky H, Schuster H, Irani S, et al. Pancreatic cancer in cystic fibrosis after bilateral lung transplantation. Pancreas. 2006;33(4):430-432. [pmid: 17079951].
47 Stalvey MS, Torrez DM, Hillan J, et al. Growth hormone therapy improves growth in children with cystic fibrosis related liver disease. J Pediatr Endocrinol. 2008;21(8):793-797.
48 Kraemer R, Rudeberg A, Hadorn B, et al. Relative underweight in cystic fibrosis and its prognostic value. Acta Paediatr Scand. 1978;67(1):33-37. [pmid: 626067].
49 Huang NN, Schidlow DV, Szatrowski TH, et al. Clinical features, survival rate, and prognostic factors in young adults with cystic fibrosis. Am J Med. 1987;82(5):871-879. [pmid: 3578357].
50 Corey M, McLaughlin FJ, Williams M, et al. A comparison of survival, growth, and pulmonary function in patients with cystic fibrosis in Boston and Toronto. J Clin Epidemiol. 1988;41(6):583-591. [pmid: 3260274].
51 Kerem E, Reisman J, Corey M, et al. Prediction of mortality in patients with cystic fibrosis. N Engl J Med. 1992;326(18):1187-1191. [pmid: 1285737].
52 Nixon PA, Orenstein DM, Kelsey SF, et al. The prognostic value of exercise testing in patients with cystic fibrosis. N Engl J Med. 1992;327(25):1785-1788. [pmid: 1435933].
53 Sharples L, Hathaway T, Dennis C, et al. Prognosis of patients with cystic fibrosis awaiting heart and lung transplantation. J Heart Lung Transplant. 1993;12(4):669-674. [pmid: 8369328].
54 Ciriaco P, Egan TM, Cairns EL, et al. Analysis of cystic fibrosis referrals for lung transplantation. Chest. 1995;107(5):1323-1327. [pmid: 7750326].
55 Corey M, Farewell V. Determinants of mortality from cystic fibrosis in Canada, 1970–1989. Am J Epidemiol. 1996;143(10):1007-1017. [pmid: 8629607].
56 Corey M, Edwards L, Levison H, et al. Longitudinal analysis of pulmonary function decline in patients with cystic fibrosis. J Pediatr. 1997;131(6):809-814. [pmid: 9427882].
57 Hayllar KM, Williams SG, Wise AE, et al. A prognostic model for the prediction of survival in cystic fibrosis. Thorax. 1997;52(4):313-317. [pmid: 9196511].
58 Kadikar A, Maurer J, Kesten S. The six-minute walk test: a guide to assessment for lung transplantation. J Heart Lung Transplant. 1997;16(3):313-319. [pmid: 9087875].
59 Moorcroft AJ, Dodd ME, Webb AK. Exercise testing and prognosis in adult cystic fibrosis. Thorax. 1997;52(3):291-293. [pmid: 9093351].
60 Rosenfeld M, Davis R, FitzSimmons S, et al. Gender gap in cystic fibrosis mortality. Am J Epidemiol. 1997;145(9):794-803. [pmid: 9143209].
61 Bell SC, Bowerman AR, Davies CA, et al. Nutrition in adults with cystic fibrosis. Clin Nutr. 1998;17(5):211-215. [pmid: 10205341].
62 Milla CE, Warwick WJ. Risk of death in cystic fibrosis patients with severely compromised lung function. Chest. 1998;113(5):1230-1234. [pmid: 9596299].
63 Venuta F, Rendina EA, De Giacomo T, et al. Timing and priorities for cystic fibrosis patients candidates to lung transplantation. Eur J Pediatr Surg. 1998;8(5):274-277. [pmid: 9825236].
64 Robinson W, Waltz DA. FEV(1) as a guide to lung transplant referral in young patients with cystic fibrosis. Pediatr Pulmonol. 2000;30(3):198-202. [pmid: 10973037].
65 Vizza CD, Yusen RD, Lynch JP, et al. Outcome of patients with cystic fibrosis awaiting lung transplantation. Am J Respir Crit Care Med. 2000;162(3 Pt 1):819-825. [pmid: 10988089].
66 Liou TG, Adler FR, Fitzsimmons SC, et al. Predictive 5-year survivorship model of cystic fibrosis. Am J Epidemiol. 2001;153(4):345-352. [pmid: 11207152].
67 Sharma R, Florea VG, Bolger AP, et al. Wasting as an independent predictor of mortality in patients with cystic fibrosis. Thorax. 2001;56(10):746-750. [pmid: 11562511].
68 Emerson J, Rosenfeld M, McNamara S, et al. Pseudomonas aeruginosa and other predictors of mortality and morbidity in young children with cystic fibrosis. Pediatr Pulmonol. 2002;34(2):91-100. [pmid: 12112774].
69 Mayer-Hamblett N, Rosenfeld M, Emerson J, et al. Developing cystic fibrosis lung transplant referral criteria using predictors of 2-year mortality. Am J Respir Crit Care Med. 2002;166(12 Pt 1):1550-1555. [pmid: 12406843].
70 Oliveira MCA, Reis FJC, Oliveira EA, et al. Prognostic factors in cystic fibrosis in a single center in Brazil: A survival analysis. Pediatr Pulmonol. 2002;34:3-10. [pmid: 12112790].
71 Schaedel C, de Monestrol I, Hjelte L, et al. Predictors of deterioration of lung function in cystic fibrosis. Pediatr Pulmonol. 2002;33(6):483-491. [pmid: 12001283].
72 Stanchina ML, Tantisira KG, Aquino SL, et al. Association of lung perfusion disparity and mortality in patients with cystic fibrosis awaiting lung transplantation. J Heart Lung Transplant. 2002;21(2):217-225. [pmid: 11834350].
73 Banjar H. Morbidity and mortality data of cystic fibrosis patients. Saudi Med J. 2003;24(7):730-735. [pmid: 12883603].
74 Vedam H, Moriarty C, Torzillo PJ, et al. Improved outcomes of patients with cystic fibrosis admitted to the intensive care unit. J Cyst Fibros. 2004;3(1):8-14. [pmid: 15463881].
75 Ellaffi M, Vinsonneau C, Coste J, et al. One-year outcome after severe pulmonary exacerbation in adults with cystic fibrosis. Am J Respir Crit Care Med. 2005;171(2):158-164. [pmid: 15502116].
76 Pianosi P, Leblanc J, Almudevar A. Peak oxygen uptake and mortality in children with cystic fibrosis. Thorax. 2005;60(1):50-54. [pmid: 15618583].
77 Belkin RA, Henig NR, Singer LG, et al. Risk factors for death of patients with cystic fibrosis awaiting lung transplantation. Am J Respir Crit Care Med. 2006;173(6):659-666. [pmid: 16387803].
78 Texereau J, Jamal D, Choukroun G, et al. Determinants of mortality for adults with cystic fibrosis admitted in Intensive Care Unit: a multicenter study. Respir Res. 2006;7:14. [pmid: 16438722].
79 Courtney JM, Bradley J, Mccaughan J, et al. Predictors of mortality in adults with cystic fibrosis. Pediatr Pulmonol. 2007;42(6):525-532. [pmid: 17469153].
80 Rosenthal M. Annual assessment spirometry, plethysmography, and gas transfer in cystic fibrosis: do they predict death or transplantation. Pediatr Pulmonol. 2008;43(10):945-952. [pmid: 18781653].
81 Tantisira KG, Systrom DM, Ginns LC. An elevated breathing reserve index at the lactate threshold is a predictor of mortality in patients with cystic fibrosis awaiting lung transplantation. Am J Respir Crit Care Med. 2002;165(12):1629-1633. [pmid: 12070064].
82 Orenstein DM, Nixon PA, Ross EA, et al. The quality of well-being in cystic fibrosis. Chest. 1989;95:344-347. [pmid: 2914486].
83 Czyzewski DI, Mariotto MJ, Bartholomew LK, et al. Measurement of quality of well being in a child and adolescent cystic fibrosis population. Med Care. 1994;32(9):965-972. [pmid: 8090048].
84 Congleton J, Hodson ME, Duncan-Skingle F. Quality of life in adults with cystic fibrosis. Thorax. 1996;51(9):936-940. [pmid: 8984707].
85 de Jong W, Kaptein AA, van der Schans CP, et al. Quality of life in patients with cystic fibrosis. Pediatr Pulmonol. 1997;23(2):95-100. [pmid: 9065946].
86 Staab D, Wenninger K, Gebert N, et al. Quality of life in patients with cystic fibrosis and their parents: what is important besides disease severity?. Thorax. 1998;53(9):727-731. [pmid: 10319053].
87 Johnson JA, Connolly M, Zuberbuhler P, et al. Health-related quality of life for adults with cystic fibrosis: a regression approach to assessing the impact of recombinant human DNase. Pharmacotherapy. 2000;20(10):1167-1174. [pmid: 11034039].
88 Abbott J, Baumann U, Conway S, et al. Cross cultural differences in health related quality of life in adolescents with cystic fibrosis. Disabil Rehabil. 2001;23(18):837-844. [pmid: 11763280].
89 Powers PM, Gerstle R, Lapey A. Adolescents with cystic fibrosis: family reports of adolescent health-related quality of life and forced expiratory volume in one second. Pediatrics. 2001;107(5):E70. [pmid: 11331720].
90 Gee L, Abbott J, Conway SP, et al. Quality of life in cystic fibrosis: the impact of gender, general health perceptions and disease severity. J Cyst Fibros. 2003;2(4):206-213. [pmid: 15463875].
91 Gee L, Abbott J, Hart A, et al. Associations between clinical variables and quality of life in adults with cystic fibrosis. J Cyst Fibros. 2005;4(1):59-66. [pmid: 15752683].
92 Koscik RL, Douglas JA, Zaremba K, et al. Quality of life of children with cystic fibrosis. J Pediatr. 2005;147(3 Suppl):S64-S68. [pmid: 16202786].
93 Quittner AL, Buu A, Messer MA, et al. Development and validation of The Cystic Fibrosis Questionnaire in the United States: a health-related quality-of-life measure for cystic fibrosis. Chest. 2005;128(4):2347-2354. [pmid: 16236893].
94 Koscik RL, Shoff S, Lai H, et al. Is recovery of birth weight Z-score within 2 years of diagnosis related to quality of life in later childhood [abstract]. Pediatr Pulmonol. 2006;41(Suppl 29):400.
95 Goldbeck L, Zerrer S, Schmitz TG. Monitoring quality of life in outpatients with cystic fibrosis: feasibility and longitudinal results. J Cyst Fibros. 2007;6(3):171-178. [pmid: 16877050].
96 Riekert KA, Bartlett SJ, Boyle MP, et al. The association between depression, lung function, and health-related quality of life among adults with cystic fibrosis. Chest. 2007;132(1):231-237. [pmid: 17625085].
97 Havermans T, Colpaert K, Dupont LJ. Quality of life in patients with Cystic Fibrosis: association with anxiety and depression. J Cyst Fibros. 2008;7(6):581-584. [pmid: 18692444].
98 Havermans T, Colpaert K, Vanharen L, et al. Health related quality of life in cystic fibrosis: To work or not to work?. J Cyst Fibros. 2009;8(3):218-223. [pmid: 19328745].
99 Aris RM, Renner JB, Winders AD, et al. Increased rate of fractures and severe kyphosis: sequelae of living into adulthood with cystic fibrosis. Ann Intern Med. 1998;128(3):186-193. [pmid: 9454526].
100 Allen DB, Rundle AC, Graves DA, et al. Risk of leukemia in children treated with human growth hormone: review and reanalysis. J Pediatr. 1997;131(1 Pt 2):S32-S36. [pmid: 9255225].
101 Marx M, Beck JD, Grabenbauer GG, et al. Gonadotrophin-independent puberty in a boy with a beta-HCG-secreting brain tumour. Horm Res. 2000;54(1):44-48. [pmid: 11182635].
102 Bell J, Parker KL, Swinford RD, et al. Long-Term Safety of Recombinant Human Growth Hormone in Children. J Clin Endocrinol Metab. 2009.
103 Hardin DS, AdamsHuet B, Brown D, et al. Online Supplement to ‘Growth hormone treatment improves growth and clinical status in prepubertal children with cystic fibrosis: results of a multicenter randomized controlled trial’. J Clin Endocrinol Metab. 2006;91(12):4925-4929. [pmid: 17018651].
104 Flume PA, O’Sullivan BP, Robinson KA, et al. Cystic fibrosis pulmonary guidelines: chronic medications for maintenance of lung health. Am J Respir Crit Care Med. 2007;176(10):957-969. [pmid: 17761616].
105 Konstan MW, Morgan WJ, Butler SM, et al. Risk factors for the rate of decline in forced expiratory volume in one second in children and adolescents with cystic fibrosis. J Pediatr. 2007;151:134-139. [pmid: 17643762].
106 Zhang XJ, Chinkes DL, Sakurai Y, et al. An isotopic method for measurement of muscle protein fractional breakdown rate in vivo. Am J Physiol. 1996;270(5 Pt 1):E759-E767. [pmid: 8967463].
107 Aris R, Merkel PA, Bachrach LK, et al. Consensus statement: Guide to bone health and disease in cystic fibrosis. J Clin Endocrinol Metab. 2005;91:1888-1896. [pmid: 15613415].
108 Haworth CS, Selby PL, Adams JE, et al. Effect of intravenous pamidronate on bone mineral density in adults with cystic fibrosis. Thorax. 2001;56:314-316. [pmid: 11254825].
109 Hutler M, Beneke R. Growth hormone and exercise tolerance in patients with cystic fibrosis. Sports Med. 2004;34(2):81-90. [pmid: 14965187].
110 Nixon GM, Armstrong DS, Carzino R, et al. Clinical outcome after early Pseudomonas aeruginosa infection in cystic fibrosis. J Pediatr. 2001;138(5):699-704. [pmid: 11343046].
111 Rosenfeld M. An overview of endpoints for cystic fibrosis clinical trials: one size does not fit all. Proc Am Thoracic Soc. 2007;4(4):299-301.
112 Huang NN. The use of new antibiotic agents for chronic pulmonary disease. Pediatr Ann. 60. 1978;7(1):56-62. passim. [pmid: 619346].
113 Koscik RL, Zaremba K, Laxova A, et al. Quality of life in childhood and adolescence: do patients with CF and their parents agree? [abstract]. Pediatr Pulmonol. 2006;41(Suppl 29):399.
114 Proesmans M, Heyns L, Moons P, et al. Real life evaluation of intravenous antibiotic treatment in a paediatric cystic fibrosis centre: outcome of home therapy is not inferior. Respir Med. 2009;103(2):244-250. [pmid: 18848441].
115 Kaplan RM, Anderson JP, Wu AW, et al. The Quality of Well-being Scale. Applications in AIDS, cystic fibrosis, and arthritis. Med Care. 1989;27(3 Suppl):S27-S43. [pmid: 2921885].
116 Schluchter MD, Konstan MW, Davis PB. Jointly modelling the relationship between survival and pulmonary function in cystic fibrosis patients. Stat Med. 2002;21(9):1271-1287. [pmid: 12111878].
117 Johnson LG, Vanhook MK, Coyne CB, et al. Safety and efficiency of modulating paracellular permeability to enhance airway epithelial gene transfer in vivo. Hum Gene Ther. 2003;14(8):729-747. [pmid: 12804137].
118 Growth hormone and diabetes. Br Med J. 1971;1(5742):186.
119 Bowlby DA, Rapaport R. Safety and efficacy of growth hormone therapy in childhood. Pediatr Endocrinol Rev. 2004;2(Suppl 1):68-77. [pmid: 16456485].
120 Blethen SL, Allen DB, Graves D, et al. Safety of recombinant deoxyribonucleic acid-derived growth hormone: The National Cooperative Growth Study experience. J Clin Endocrinol Metab. 1996;81(5):1704-1710. [pmid: 8626820].
121 Cutfield WS, Wilton P, Bennmarker H, et al. Incidence of diabetes mellitus and impaired glucose tolerance in children and adolescents receiving growth-hormone treatment. Lancet. 2000;355(9204):610-613. [pmid: 10696981].
122 O’Riordan SM, Dattani MT, Hindmarsh PC. Cystic fibrosis-related diabetes in childhood. Horm Res Paediatr. 2010;73(1):15-24. [pmid: 20190536].
123 Bismuth E, Laborde K, Taupin P, et al. Glucose tolerance and insulin secretion, morbidity, and death in patients with cystic fibrosis. J Pediatr. 2008;152(4):540. Ar-545. [pmid: 18346512].
124 Ahmad T, Nelson R, Taylor R. Insulin sensitivity and metabolic clearance rate of insulin in cystic fibrosis. Metabolism. 1994;43(2):163-167. [pmid: 8121296].
125 Hardin DS, LeBlanc A, Lukenbough S, et al. Insulin resistance is associated with decreased clinical status in cystic fibrosis. J Pediatr. 1997;130(6):948-956. [pmid: 9202618].
126 Rosenecker J, Hofler R, Steinkamp G, et al. Diabetes mellitus in patients with cystic fibrosis: the impact of diabetes mellitus on pulmonary function and clinical outcome. Eur J Med Res. 2001;6(8):345-350. [pmid: 11549516].
127 Miller RJ, Tildesley HD, Wilcox PG, et al. Sex disparities in effects of cystic fibrosis-related diabetes on clinical outcomes: a matched study. Can Respir J. 2008;15(6):291-294. [pmid: 18818782].
128 Milla CE, Billings J, Moran A. Diabetes is associated with dramatically decreased survival in female but not male subjects with cystic fibrosis. Diabetes Care. 2005;28(9):2141-2144. [pmid: 16123480].
129 Moran A, Dunitz J, Nathan B, et al. Cystic fibrosis-related diabetes: current trends in prevalence, incidence, and mortality. Diabetes Care. 2009;32(9):1626-1631. [pmid: 19542209].
130 Godbout A, Hammana I, Potvin S, et al. No relationship between mean plasma glucose and glycated haemoglobin in patients with cystic fibrosis-related diabetes. Diabetes Metab. 2008;34(6 Pt 1):568-573. [pmid: 18922724].
131 Pfizer I. Genotropin^®^ (somatropin [rDNA origin] for injection) package insert.
132 Serono I. Saizen^®^ (somatropin [rDNA origin] for injection) package insert.
133 Genentech I. Nutropin^®^ (somatropin [rDNA origin] for inection) package insert.
134 Neglia JP, Wielinski CL, Warwick WJ. Cancer risk among patients with cystic fibrosis. J Pediatr. 1991;119(5):764-766. [pmid: 1941382].
135 Neglia JP, FitzSimmons SC, Maisonneuve P, et al. The risk of cancer among patients with cystic fibrosis. Cystic Fibrosis and Cancer Study Group. N Engl J Med. 1995;332(8):494-499. [pmid: 7830730].
136 Maisonneuve P, FitzSimmons SC, Neglia JP, et al. Cancer risk in nontransplanted and transplanted cystic fibrosis patients: a 10-year study. J Natl Cancer Inst. 2003;95(5):381-387. [pmid: 12618503].
137 Jenkins PJ, Mukherjee A, Shalet SM. Does growth hormone cause cancer? [see comment]. Clin Endocrinol (Oxford). 2006;64(2):115-121.
138 Massoner P, Colleselli D, Matscheski A, et al. Novel mechanism of IGF-binding protein-3 action on prostate cancer cells: inhibition of proliferation, adhesion, and motility. Endocr Relat Cancer. 2009;16(3):795-808. [pmid: 19509068].
139 Ma J, Pollak MN, Giovannucci E, et al. Prospective study of colorectal cancer risk in men and plasma levels of insulin-like growth factor (IGF)-I and IGF-binding protein-3. J Natl Cancer Inst. 1999;91:620-625. [pmid: 10203281].
140 Schernhammer ES, Holly JM, Hunter DJ, et al. Insulin-like growth factor-I, its binding proteins (IGFBP-1 and IGFBP-3), and growth hormone and breast cancer risk in the Nurses Health Study II. Endocrine-Related Cancer. 2006;13:583-592. [pmid: 16728584].
141 Renehan AG, Zwahlen M, Minder C, et al. Insulin-like growth factor (IGF)-I, IGF binding protein-3, and cancer risk: systematic review and meta-regression analysis. Lancet. 2004;363(9418):1346-1353. [pmid: 15110491].
142 Laursen EM, Juul A, Lanng S, et al. Diminished concentrations of insulin-like growth factor I in cystic fibrosis. Arch Dis Child. 1995;72(6):494-497. [pmid: 7618932].
143 Hardin DS, Ahn C, Schnabel D. International meta-analysis of GH in cystic fibrosis. Hormone research. 2009;72:252. [pmid: 19786797].
144 von Tirpitz C, Reinshagen M. Management of osteoporosis in patients with gastrointestinal diseases. Eur J Gastroenterol Hepatol. 2003;15(8):869-876. [pmid: 12867796].