# Summary and Discussion

A succinct summary of evidence on benefits and harms of using rhGH therapy in patients with CF in addition to usual care is presented in Table 31. More elaborate discussions are provided at the end of the results for each Key Question. More detailed assessments of strength of evidence for major clinical outcomes and harms are summarized in an EPC grading table of evidence (Appendix Tables F9–F12). Key Questions 1 and 2 focus on benefits while Key Question 4 focuses on nonmalignant harms and Key Question 6 focuses on malignancy. Benefits evaluated for included: pulmonary function (percent predicted FEV_1_ and change in FEV_1_), growth (height, weight, lean body mass, protein turnover), exercise tolerance, bone mineralization, frequency of required intravenous antibiotic treatments, frequency of hospitalization, quality of life, bone fracture or development of osteoporosis/osteopenia, or total mortality. Harms evaluated for included: glucose intolerance, diabetes, hypoglycemia, and malignancy. Members of the TEP identified these outcomes as important because they are most likely relevant to patients, clinicians, and policymakers. Key question 3 explored the associations between intermediate outcomes and final health outcomes. Key Questions 6 and 7 focused on factors that might impact the efficacy of rhGh in patients with CF or subpopulations that might receive rhGH therapy.

Table 31 Summary of results

Outcome | Type of Study | Number of Studies | Pooled | Conclusion | Strength of Evidence
KQ1. In patients with CF, does treatment with rhGH as an adjuvant to usual care improve intermediate outcomes, including: pulmonary function; growth (height, weight, lean body mass, protein turnover); exercise tolerance; and bone mineralization, compared with usual care alone?
Pulmonary Function
Absolute FVC | Controlled | 3 | Yes | rhGH better than control | Moderate
Absolute FVC | Single-arm | 1 | No | No effect | Insufficient
Percent predicted FVC | Controlled | 5 | Yes | rhGH better than control | Low
Percent predicted FVC | Single-arm | 2 | No | Mixed results from baseline | Insufficient
Absolute FEV_1_ | Controlled | 4 | Yes | rhGH better than control | Moderate
Absolute FEV_1_ | Single-arm | 1 | No | No effect | Insufficient
Percent predicted FEV_1_ | Controlled | 4 | Yes | No effect | Moderate
Percent predicted FEV_1_ | Single-arm | 2 | No | No effect | Insufficient
FEV_1_ Z-score | Controlled | 1 | Yes | No effect | Insufficient
FEV_1_ Z-score | Single-arm | No data are available | | | Insufficient
Anthropometrics
Height | Controlled | 3 | Yes | rhGH better than control | Low
Height | Single-arm | 1 | No | Improvement from baseline | Insufficient
Height velocity | Controlled | 3 | Yes | rhGH better than control | Moderate
Height velocity | Single-arm | 4 | No | Improvement from baseline | Insufficient
Height Z-score | Controlled | 3 | Yes | rhGH better than control | Moderate
Height Z-score | Single-arm | 3 | No | Improvement from baseline | Low
Height percentile | Controlled | 1 | No | rhGH better than control | Insufficient
Height percentile | Single-arm | No data are available | | | NA
Weight | Controlled | 5 | Yes | rhGH better than control | Moderate
Weight | Single-arm | 1 | No | Improvement from baseline | Insufficient
Weight velocity | Controlled | 2 | Yes | rhGH better than control | Moderate
Weight velocity | Single-arm | 3 | No | No effect | Low
Weight Z-score | Controlled | 4 | Yes | No effect | Low
Weight Z-score | Single-arm | 1 | No | Improvement from baseline | Insufficient
Weight percentile | Controlled | 1 | No | rhGH better than control | Insufficient
Weight percentile | Single-arm | No data are available | | | Insufficient
Body mass index | Controlled | 2 | Yes | rhGH better than control | Moderate
Body mass index | Single-arm | 1 | No | No effect | Insufficient
BMI Z-score | Controlled | 1 | Yes | No effect | Insufficient
BMI Z-score | Single-arm | No data are available | | | Insufficient
Percent IBW | Controlled | 2 | Yes | rhGH better than control | Low
Percent IBW | Single-arm | No data are available | | | Insufficient
Lean body mass | Controlled | 8 | Yes | rhGH better than control | Moderate
Lean body mass | Single-arm | No data are available | | | Insufficient
Protein Markers
Various | Controlled | 2 | No | Mixed results | Insufficient
Various | Single-arm | 1 | No | No effect | Insufficient
Exercise Tolerance
Various | Controlled | 3 | No | No effect | Insufficient
Various | Single-arm | 1 | No | No effect | Insufficient
Bone Mineralization
Bone age | Controlled | 2 | No | No effect | Insufficient
Bone age | Single-arm | 3 | No | No effect | Low
BMC | Controlled | 4 | Yes | rhGH better than control | Low
BMC | Single-arm | No data are available | | | Insufficient
BMC Z-score | Controlled | 1 | No | rhGH better than control | Insufficient
BMC Z-score | Single-arm | No data are available | | | Insufficient
Sexual Maturation
| Controlled | 7 | No | rhGH better than control | Low
| Single-arm | No data are available | | | Insufficient
KQ2. In patients with CF, does treatment with rhGH as an adjuvant to usual care improve health outcomes, including: frequency of required intravenous antibiotic treatments; frequency of hospitalization; quality of life; bone fracture or development of osteoporosis/osteopenia; or mortality, compared with usual care alone?
Antibiotic Usage | Controlled | 3 | No | rhGH better than control | Insufficient
Antibiotic Usage | Single-arm | No data are available | | | Insufficient
Pulmonary Exacerbations | Controlled | 1 | No | No effect | Insufficient
Pulmonary Exacerbations | Single-arm | No data are available | | | Insufficient
Hospitalization Rate | Controlled | 4 | Yes | rhGH better than control | Moderate
Hospitalization Rate | Single-arm | No data are available | | | Insufficient
HRQoL | Controlled | 2 | No | rhGH better than control | Insufficient
HRQoL | Single-arm | No data are available | | | Insufficient
Bone Consequences | No data are available. | | | | Insufficient
Mortality | No data are available. | | | | Insufficient
KQ3. In patients with CF, what is the strength of evidence that intermediate outcomes of pulmonary function, growth, and bone mineralization are associated with improvements in health outcomes of quality of life, bone fracture or development of osteoporosis/osteopenia, or mortality?
Mortality
Pulmonary function | Observational | 28 | No | Mixed results | NA
Anthropometrics | Observational | 26 | No | Mixed results | NA
Protein turnover | Observational | No data are available | | | NA
Exercise tolerance | Observational | 10 | No | Mixed results | NA
Bone mineralization | Observational | No data are available | | | NA
HRQoL
Pulmonary function | Observational | 14 | No | Improved pulmonary function relates to improved HRQoL | NA
Anthropometrics | Observational | 10 | No | Mixed results | NA
Protein turnover | Observational | No data are available | | | NA
Exercise tolerance | Observational | 2 | No | Improved exercise tolerance relates to improved HRQoL | NA
Bone mineralization | Observational | No data are available | | | NA
Bone Consequences
Pulmonary function | Observational | 1 | No | No association found | NA
Anthropometrics | Observational | 1 | No | No association found | NA
Protein turnover | Observational | No data are available | | | NA
Exercise tolerance | Observational | No data are available | | | NA
Bone mineralization | Observational | No data are available | | | NA
KQ4. In patients with CF, what is the frequency of nonmalignant serious adverse effects resulting from treatment with rhGH in patients with CF? Adverse effects of interest include, but are not limited to: glucose intolerance, diabetes, and hypoglycemia.
Glucose Parameters
A1c | Controlled | 2 | Yes | No effect | Low
A1c | Single-arm | 2 | No | Nonsignificant increases from baseline | Low
Random BG | Controlled | 3 | Yes | Glucose levels remained stable | Insufficient
Random BG | Single-arm | No data are available | | | Insufficient
Fasting BG | Controlled | 2 | Yes | Increased with rhGH compared to control | Moderate
Fasting BG | Single-arm | 1 | No | No effect | Insufficient
Stimulated BG | Controlled | 1 | Yes | No effect | Insufficient
Stimulated BG | Single-arm | No data are available | | | Insufficient
Postprandial BG | Controlled | 1 | Yes | No effect | Insufficient
Postprandial BG | Single-arm | No data are available | | | Insufficient
Glucose Intolerance
| Controlled | 7 | No | No patients developed | Low
| Single-arm | 3 | No | Few patients developed | Insufficient
Diabetes
| Controlled | 7 | No | No patients developed | Low
| Single-arm | 1 | No | One case report of diabetes | Insufficient
Injection Site Reactions
| Controlled | No data are available | | | NA
| Single-arm | 2 | No | Minor discomfort and bruising reported | NA
Liver Transaminases
| Controlled | No data are available | | | NA
| Single-arm | 2 | No | Limited report of liver transaminase elevations | NA
Study Withdrawals
| Controlled | 10 | No | Majority of trials reported no withdrawals | NA
| Single-arm | No data are available | | | NA
KQ5. What is the risk of malignancy associated with rhGH use as determined by: (a) markers of cancer risk with rhGH (IGF-I increases over 100 ng/ml or IGFBP-3 decreases over 1000 ng/ml) from studies of rhGH in people with CF and by (b) assessment of evidence on cancer incidence from non-CF patients receiving modest doses of rhGH (0.2mg/kg/week to 0.6mg/kg/week) for disorders such as growth hormone deficiency and idiopathic short stature?
Biomarkers
IGF-I | Controlled | 4 | No | rhGH increases more than control | Insufficient
IGF-I | Single-arm | 2 | No | Increased from baseline | Insufficient
IGFBP-3 | Controlled | 1 | No | rhGH increases more than control | Insufficient
IGFBP-3 | Single-arm | 1 | No | Increased from baseline | Insufficient
Cancer Incidence in CF Patients
| Controlled | No data are available | | | Insufficient
| Single-arm | 1 | No | Case report shows probable relationship between rhGH and cancer | Insufficient
Cancer in non-CF Patients
| Controlled | No data are available | | | Insufficient
| Single-arm | 3 | No | Insufficient data to conclude on rhGH effect on cancer | Low
KQ6. In patients with CF, how is efficacy, effectiveness, safety or adverse events impacted by rhGH dose, therapy duration, baseline nutritional status, and concurrent medical therapies?
Dose | Controlled | 1 | No | No significant differences between dose groups in endpoints | NA
Duration | Controlled | 9 | Yes | One year therapy trends towards improved efficacy versus 6 months therapy. One year therapy trends towards increased glucose parameters versus 6 months therapy. | NA
Baseline nutritional status | Controlled | 1 | No | There is limited evidence in patients with variable nutritional status. Efficacy exists in patients receiving enteral nutrition. | NA
Concurrent medical therapies | Controlled | No data are available | | | NA
KQ7. In patients with CF, how do the efficacy, effectiveness, safety or adverse events of treatment with rhGH differ between subgroups of patients? Subgroup characteristics of interest include, but are not limited to: age (pre-pubertal, pubertal, post-pubertal); gender; baseline clinical status (height, weight, lean body mass, pulmonary function, exercise tolerance, nutritional status); and/or the nature, extent, and effectiveness of prior treatment.
Age | Controlled | 6 | Yes | Pubertal patients may derive greater benefit in pulmonary function, weight, and bone mineral content than prepubertal patients. Prepubertal patients may derive greater benefit in height than pubertal patients. | NA
Gender | Controlled | 3 | Yes^a^ | Females (both prepubertal and pubertal) may experience greater benefit in height and weight than males. | NA
Baseline clinical status | Controlled | 2 | No | Patients with lower baseline height Z-score experienced greater height improvement than those with higher height Z-score. Higher baseline weight was correlated with greater improvement in pulmonary function. | NA
Prior treatment | No data are available | | | | NA

Legend: A1c=glycosylated hemoglobin; BG=blood glucose; BMC=bone mineral content; BMI=body mass index; CF=cystic fibrosis; FEV1=forced expiratory volume in one second; FVC=forced vital capacity; HRQoL=health-related quality-of-life; %IBW=percent ideal body weight; IGF-I=insulin-like growth factor-1; IGFBP-3=insulin-like growth factor binding protein-3; NA=not assessed

a Data pooled from three trials by Vanderwel and Hardin.

## Future Research

### Limitations of Current Research

While rhGH is a promising therapy for the treatment of CF there are a number of important research questions that should be answered before its role can truly be discerned.

In our analysis, we found improvements in height, weight, bone mineral content, and a few but not all measures of pulmonary function with rhGH therapy, but we do not know if this translates into fewer hospitalizations, deaths, or bone fractures or if therapy improves HRQoL in a meaningful way. Most of the trials compared rhGH therapy to no therapy rather than to placebo or an active control and did not rigorously assess for harms. Since the controlled trials were limited to malnourished patients with CF receiving supplemental nutrition who have impaired baseline growth indices, the results cannot be extrapolated to the normal growing patient, patients with CF who are otherwise healthy, or those who are malnourished but not receiving nutrition. While studies suggest that the risk of glucose metabolism problems with rhGH is low (based on A1c concentrations), longer durations of therapy may increase the risk of glucose intolerance more than shorter durations (based on glucose concentrations). RhGH also increases the concentrations of IGF-I, which may indicate an increased risk of neoplasms, but this is speculative.

The systematic review and meta-analysis conducted in this report are limited by the available literature. To date, the randomized controlled trial conducted by Stalvey and colleagues has not been published and the data is only available in abstract form.39 We opted to include this valuable data in our analysis due to the small numbers of controlled trials available. Analyses may need to be updated upon the publication of the full manuscript for this trial, as data on more endpoints may become available. Secondly, we included both randomized controlled trials and observational cohort studies in the category of controlled trials; this was done because both sets of studies compared rhGH therapy to a control group. Additionally, the one retrospective study by Hardin and colleagues described prospective follow-up methods similar to that seen in randomized controlled trials.34 In some cases, the extrapolation of numerical data from figures was necessary to report and analyze the data when numerical data was not available either in the manuscript or upon contacting the authors. Data was extracted from figures in duplicate, after digitally enlarging figures and superimposing gridlines.

The data linking improvements in pulmonary function with reductions in final health outcomes in CF patients is most apparent with percent predicted FEV_1_. However, treatment with rhGH only nonsignificantly increases percent predicted FEV_1_. In addition, preliminary data suggests that pubertal/adolescent patients may derive more pulmonary benefits from rhGH therapy than prepubertal patients even though there are dissimilar increases in height. This suggests that improvements in pulmonary function may not be tied directly to improvements in height and that the target population for rhGH therapy needs to be further explored.

In patients with osteoporosis but without CF, therapy with bisphosphonates improves bone mineralization with reductions in bone fractures.144 However, sodium fluoride treatment dramatically increases bone mineral content but may not reduce vertebral fractures, and in high doses, may increase the risk of nonvertebral fractures.144 As such, it cannot be simply assumed that improvements in bone mineralization will reduce bone fractures and complications such as death.144

Based on these research gaps we propose the following avenues for future research.

### Future Avenues for Research

#### Individual Patient Data Meta-Analysis

- We believe that an individual patient data meta-analysis of completed trials evaluating rhGH therapy in patients with CF would yield important information if original trial investigators were willing to report on hospitalizations, deaths, or bone fractures. We attempted to contact all of the authors and explicitly ask for any information they had on these final health outcomes but were unsuccessful.
- An individual patient data meta-analysis may allow the determination of the benefits of rhGH therapy in patients with varying levels of nutritional status, pubertal status, age, and concurrent medical therapy; all important unanswered questions.

#### Clinical Trials

- We believe that a large, multicenter, randomized, placebo-controlled trial should be conducted to determine the impact of rhGH therapy on hospitalizations, mortality, bone fractures, and HRQoL.
  ○ Such a trial should be powered and conducted to analyze data in pubertal and prepubertal patients separately.
  ○ It may be worthwhile for the Cystic Fibrosis Foundation and key trialists to appoint a working group and establish a network of sites interested in prospectively evaluating the impact of rhGH in patients with CF so that such as trial could be conducted. The working group could also specify the HRQoL scale to be used in the trial.
- Even if a large multicenter trial is not feasible, we suggest that smaller future trials evaluating the impact of rhGH in patients with CF should be placebo controlled and prospectively collect data on hospitalizations, mortality, bone fractures, and HRQoL and report on their results even if they are not powered to be quantitatively analyzed.
  ○ There is value in conducting smaller scale trials with primary objectives to discern the impact of rhGH on pulmonary parameters, exercise tolerance, and HRQoL. While there was no significant improvement in percent predicted FEV_1_ or exercise tolerance in our CER, there were qualitative improvements, and future studies would allow us to determine if these were real but underpowered effects.
  ○ For exercise tolerance and HRQoL, the Cystic Fibrosis Foundation and trialists should specify which exercise tolerance tests and HRQoL questionnaires should be used across future studies to facilitate pooling.
  ○ Like with the evaluation of benefits, future trials should prespecify the harms they will assess and report on their results even if they are underpowered to perform quantitative synthesis.
  ○ Trials with treatment durations of 6 or 12 months or longer would be helpful in subsequently determining the adequate duration of therapy.

#### Observational Studies

- Future observational trials should evaluate the relationship between:
  ○ The absolute change in FEV_1_ and final health outcomes in patients with CF.
  ○ Bone mineralization and final health outcomes in patients with CF.
  ○ IGF-I concentrations on the occurrence of cancer in patients with CF.
  ○ Long-term (5–10 year) consequences of rhGH therapy on diabetes or malignancy in patients with CF.