# Methods

## Topic Development

The topic for this report was nominated in a public process. With input from technical experts, the Scientific Resource Center (SRC) for the AHRQ Effective Health Care Program drafted the initial key questions and, after approval from AHRQ, posted them to a public Web site. The UCONN/HH EPC drafted a topic refinement document with proposed key questions after consult with key experts in the field. The public was invited to comment on the topic refinement document and key questions. After reviewing the public commentary, the final key questions were approved by AHRQ.

## Analytic Framework

To guide our assessment of studies examining the association rhGH on benefits and harms in our target population, we developed an analytic framework mapping specific linkages from comparisons to subpopulations of interest, mechanisms of benefit, and outcomes of interest (Figure 1). It is a logic chain that supports the link from the intervention to the outcomes of interest. Intermediate outcomes are those which may be evaluated in the literature, but are not final health outcomes in themselves.

Figure 1 Analytic framework

Legend: KQ=key question; rhGH=recombinant human growth hormone

Narrative: Figure 1 shows the analytic framework of this report. In patients with cystic fibrosis and relevant subgroups based upon gender, age, baseline clinical status, and prior therapy, we seek to answer the effect that intervention with rhGH may have. The first step in the analytic framework deals with intermediate outcomes from rhGH treatment, which includes IGF factors, protein turnover markers, nutritional status, anthropometrics, bone measures, pulmonary function, pulmonary exacerbations, exercise tolerance, antibiotic use, sex hormones and pubertal development. Final health outcomes can either be answered from the direct evidence that exists in cystic fibrosis patients treated with rhGH or by assessing the link between intermediate and final health outcomes (which include health-related quality-of-life, hospitalization, bone fracture, or mortality). Adverse events associated with rhGH use are also evaluated, including altered glucose metabolism, development of diabetes mellitus, lymphoid overgrowth, or malignancy.

## Literature Search Strategy

Two independent investigators conducted systematic literature searches of MEDLINE (starting from 1950), the Cochrane Central Register of Controlled Trials (CENTRAL), and the Cochrane Database of Systematic Reviews from the earliest possible date through April 2010. Three separate searches were conducted. The first search was used to identify trials and studies which explicitly evaluated the impact of rhGH on outcomes in patients with CF. The two other searches were used to answer key questions 3 (where the impact of surrogate markers on terminal endpoints in patients with CF are evaluated) and 5 (where the malignant effects of rhGH are assessed in a CF population and those with idiopathic short stature or growth hormone deficiency). With the searches for key questions 3 and 5, we utilized Cochrane’s Highly Sensitive Search Strategy (Sensitivity Maximizing Version 2008)18 to limit to randomized controlled trials and the Scottish Intercollegiate Guidelines Network Observational Study Search Filter to limit to observational studies. No language restrictions were imposed. In addition, a manual search of references from reports of clinical trials or review articles was conducted. The complete search strategy is included in Appendix A.

## Study Selection

Studies were included in the evaluation of key questions 1, 2, 4, 6, and 7 if they were (1) studies of rhGH therapy, (2) conducted in patients with CF, (3) studies that reported data on pre-specified clinical or humanistic outcomes (Figure 1), and (4) reports of new discovery (specifically, randomized controlled trials, observational trials, systematic review/meta-analyses, or case reports). Studies were included in the key question 3 evaluation if they were (1) conducted in patients with CF, (2) either randomized controlled trials or observational studies, and (3) report linkages between intermediate outcomes and health outcomes. Studies which reported on linkages between intermediate outcomes and health outcomes subsequent to a medical or behavioral intervention were excluded from this evaluation. Studies were included in the key question 5 evaluation if they were (1) studies of rhGH therapy, (2) conducted in patients with CF, idiopathic short stature, or growth hormone deficiency, (3) either randomized controlled trials or observational studies, and (4) studies that reported data on malignant outcomes.

## Validity Assessment

Validity assessment was performed using the recommendations in the EPC Methods Guide. Each study was assessed for the following individual criteria: comparable study groups at baseline, detailed description of study outcomes, blinding of subjects, blinding of outcome assessors, intent-to-treat analysis, description of participant withdrawals, and potential conflict of interest. Additionally, randomized controlled trials were assessed for randomization technique and allocation concealment. Observational studies were assessed for sample size, participant selection method, exposure measurement method, potential design biases, and appropriate analyses to control for confounding. Studies were then given an overall score of good, fair, or poor. (Table 1) This rating system does not attempt to assess the comparative validity across different types of study design. For example, a “fair” controlled trial is not judged to have the same methodologic criteria as a “fair” single-arm observational study. Both study design and quality rating should be considered when interpreting the methodological quality of a study.

Table 1 Summary ratings of quality of individual studies

Quality Rating | Definition
Good (low risk of bias) | These studies have the least bias and results are considered valid. A study that adheres mostly to the commonly held concepts of high quality include the following: a formal randomized, controlled study; clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; less than 20 percent dropout; and clear reporting of dropouts.
Fair | These studies are susceptible to some bias, but it is not sufficient to invalidate results. They do not meet all the criteria required for a rating of good quality because they have some deficiencies, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems.
Poor (high risk of bias) | These studies have significant flaws that imply biases of various types that may invalidate the results. They have serious errors in design, analysis, or reporting; large amounts of missing information, or discrepancies in reporting.

## Data Abstraction

Through the use of a standardized data abstraction tool (Appendix B), two reviewers independently collected data, with disagreement resolved through discussion. The following information was obtained from each trial, where applicable: author identification, year of publication, source of study funding, study design characteristics and methodological quality criteria, study population [including study inclusion and exclusion criteria, run-in period, study withdrawals, dose of rhGH utilized, length of study, duration of patient followup, and disease state (CF, idiopathic short stature, or growth hormone deficiency)], patient baseline characteristics (sex, age, ethnicity, nutritional status), comorbidities, and use of concurrent standard medical therapies (corticosteroids, antibiotics, etc). Endpoints included: pulmonary function, anthropometrics (height, weight, lean body mass, protein turnover), exercise tolerance, intravenous antibiotic use, hospitalizations, HRQoL, bone mineralization, bone fracture or development of osteoporosis/osteopenia, mortality, glucose measures, and development of diabetes or malignancy.

All authors were contacted for unpublished data. A standardized letter was sent to explain the purpose of our project and include a template with all available outcomes of interest. The template was provided to the author with their published trial or study-specific data filled in and the author was invited to provide any additional data.

## Literature Synthesis

The key questions follow the analytic framework along the continuum of intermediate to final health outcomes. Our review continues with this organizational scheme and answers each key question independently.

Regarding the intermediate outcomes within KQ1, there are distinct clusters of outcomes which may be reported in a variety of ways. For pulmonary function, trials and studies report a wide range of outcomes, such as absolute values of FEV_1_ and FVC along with the percent-predicted FEV_1_ and FVC. The most commonly reported of these were selected for meta-analysis, while the remaining outcomes were reported qualitatively.

Anthropometrics are also reported in many ways, including absolute values of height, height percentile, weight Z-scores, weight velocity, and weight for height Z-scores. Because of the variation in reporting, not all of these outcomes were meta-analyzed. While each has merit in clinical interpretation, data handling is difficult. When given multiple height and weight outcomes, the most commonly reported outcomes were selected for meta-analysis and the rest were qualitatively described. Absolute changes in height and weight over a broad age range may be difficult to interpret, as younger children may exhibit more rapid growth than adolescents. Therefore, to place clinical perspective on data that is reported as absolute change in height and weight, we modeled conversions of this data to Z-score data using the WHO AnthroPlus software19 and growth charts published by the CDC.20

Final health outcomes in KQ2 and adverse events in KQ4 associated with rhGH were meta-analyzed when data was adequate. The remaining KQs (3, 5–7) were answered qualitatively.

## Quantitative Analysis

Randomized controlled trials and prospective cohort studies were pooled together when trials evaluated both an rhGH and a control group, henceforth described as controlled trials. Single-arm observational studies were described qualitatively in all cases. In this systematic review, some of the data allowed for meta-analyses to pool the data. When pooling continuous endpoints, weighted mean differences (WMD) along with 95 percent confidence intervals were calculated using a DerSimonian and Laird random effects model.21 In cases where mean change scores from baseline for each group were not reported, we calculated the difference between the mean baseline and mean followup scores for each group. Standard deviations (SDs) of the change scores were calculated from the SD of the baseline values and of the followup values, using the formula: SD_baseline-followup_=sqrt(SD^2^ _baseline_ + SD^2^_followup_ −2*(correlation coefficient)SD_baseline_*SD_followup_). A correlation coefficient of 0.5 proposed by Follman and colleagues was used.22 In the event where there was more than one treatment group versus control, each treatment group was treated as a separate trial for meta-analysis, dividing the control group equally among treatment arms.18

For dichotomous endpoints, weighted averages were reported as relative risks (RRs) with associated 95 percent confidence intervals (CIs). As heterogeneity between included studies was expected, a DerSimonian and Laird random-effects model was used when pooling data and calculating RRs and 95 percent CIs.

Statistical heterogeneity was addressed using the I^2^ statistic (which assesses the degree of inconsistency not due to chance across studies and ranges from 0–100 percent with the higher percentage representing a higher likelihood of the existence of heterogeneity) evaluations. While categorization of values for I^2^ may not be appropriate in all situations, I^2^ values of 25 percent, 50 percent and 75 percent have been regarded as representative of low, medium and high statistical heterogeneity, respectively. Visual inspection of funnel plots and Egger’s weighted regression statistics were used to assess for the presence of publication bias.

Statistics were performed using StatsDirect statistical software, version 2.4.6 (StatsDirect Ltd, Cheshire, England). A p-value of <0.05 was considered statistically significant for all analyses.

## Subgroup and Sensitivity Analyses

To assess the effect of heterogeneity on our meta-analysis’ conclusions, subgroup and sensitivity analyses were conducted. Subgroup analyses were conducted to assess the effect of treatment duration and patient pubertal status on the efficacy of rhGH. Trials with duration of 6 months were meta-analyzed separately from trials with duration of one year. Trials which enrolled prepubertal patients were meta-analyzed and compared to the one trial which enrolled pubertal patients alone. Trials which enrolled patients with a range of pubertal status were excluded in subgroup analysis.

## Grading the Strength of Evidence

We used the EPC methodology for grading, which is based on the criteria and methods of GRADE (Grading of Recommendations Assessment, DEvelopment) to assess the strength of evidence. This system uses four required domains—risk of bias, consistency, directness, and precision.23

Additional domains were not utilized because they were deemed not relevant to this review. All assessments were made by two investigators (with disagreements resolved through discussion). The evidence pertaining to each key question was classified into four broad categories: (1) “high”, (2) “moderate”, (3) “low”, or (4) “insufficient” grade (Table 2). Below we describe in more detail the features that determined the strength of evidence for the different outcomes evaluated in this report.

Table 2 Definitions for grading the strength of evidence

Grade | Definition
High | There is high confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and is likely to change the estimate.
Insufficient | Very low confidence that the evidence reflects the true effect. Any estimate of effect is very uncertain. Also, evidence either is unavailable or does not permit estimation of an effect

### Risk of Bias

Risk of bias is the degree to which the included studies for any given outcome or comparison have a high likelihood of adequate protection against bias. This can be assessed through the evaluation of both design and study limitations. For study design, whether the study was a randomized controlled trial or an observational study was recorded. Studies were also ranked as no limitations, serious limitations, or very serious limitations. Because all of the included studies were randomized controlled trials with few limitations, they were considered to have a low risk of bias.

### Consistency

Consistency refers to the degree of similarity in the direction of the effect sizes from included studies within an evidence base. This was assessed in two main ways: (1) the effect sizes had the same sign, in that they were on the same side of unity; (2) the range of effect sizes was narrow. We ranked this domain as no inconsistency, serious inconsistency, and very serious inconsistency. For outcomes whereby only a single study was included, consistency would not be judged. We also considered measures of heterogeneity from our meta-analyses in evaluating consistency.

### Directness

Directness refers to whether the evidence links the compared interventions directly with health outcomes, and compares two or more interventions in head-to-head trials. Indirectness implies that more than one body of evidence is required to link interventions to the most final health outcomes. We ranked this domain as no indirectness, serious indirectness, and very serious indirectness.

### Precision

Precision refers to the degree of certainty surrounding an effect estimate with respect to a given outcome. For example, when a meta-analysis was performed, we evaluated the confidence interval around the summary effect size. A precise estimate is an estimate that would allow a clinically useful conclusion. An imprecise estimate is one for which the confidence interval is wide enough to include clinically distinct conclusions (e.g. both clinically important superiority and inferiority), a circumstance that will preclude a conclusion.

## Peer Review and Public Commentary

A draft of this Evidence Report was sent to peer reviewers, the representatives of the AHRQ and the SRC at Oregon Health and Science University. The draft report and posted to the Effective Health Care website for public comment. In response to the comments of the peer reviewers and the public, revisions were made to the Evidence Report, and a summary of the comments and their disposition was submitted to AHRQ.