# Introduction

## Definition and Prevalence of Cystic Fibrosis

Cystic fibrosis (CF) is a life-threatening childhood-onset genetic disease in the United States, affecting approximately 30,000 people in the United States.1,2 It is most common among Caucasians, occurring in approximately 1 per 2,500 Caucasian births, compared with 1 per 15,100 African-American births and between 1 per 31,000 to 1 per more than 100,000 Asian-American births.3 CF is carried as an autosomal recessive trait in approximately 10 million Americans, and in approximately 3 percent of the Caucasian population. The gene responsible for CF encodes the cystic fibrosis transmembrane regulator (CFTR) protein, which regulates sodium and chloride transport across epithelial membranes. Defects in the CFTR protein result in a multisystem disorder affecting nearly all exocrine glands, with abnormally viscous mucus and excessive secretions. The dominant clinical features are chronic lung disease and pancreatic insufficiency with poor nutrition and poor growth.4,5

Treatment has improved considerably over the past 25 years, resulting in improvements in measures of nutrition, pulmonary function, and mortality among children and adolescents with CF. The median age of survival has improved consistently from the 1950s to the most recent data in 2008 (age 37.4 years).2 The estimated annual direct medical costs per CF patient are more than $40,000, with an estimated $9,000 in secondary costs per year per patient.6

## Complications Associated With Cystic Fibrosis

Although the morbidity and mortality associated with CF is most directly due to progressive lung disease, growth and nutritional indices (weight-for-age, height-for-age, and percent ideal body weight) have been shown to be predictive of future pulmonary function in children with CF.7 It has been suggested that improvement of linear growth in children with CF may allow more lung mass and better pulmonary function, independent of improved weight gain.8,9

Poor weight and shorter height have also been shown to be independently associated with increased morbidity and mortality in CF patients.7–11 Pulmonary function is most commonly assessed by forced expiratory volume in one second (FEV_1_), which is the volume of air forcefully exhaled in one second, and forced vital capacity (FVC), which is the total volume of air that can be exhaled forcefully after a deep inhalation.12 Both of these values can be reported as absolute values or as the percent of the predicted value based upon a patient’s height.12 Absolute changes in FEV_1_ or FVC can be sensitive to changes in pulmonary function, but they do not account for changes in pulmonary function with regard to changes in height. Percent predicted values are useful in comparisons between patients of different height or age because it normalizes these variables. However, issues arise in its clinical interpretation because of its basis on height; a CF patient with poor pulmonary function combined with short stature may exhibit a normal percent predicted FEV_1_5

While both have some limitations, both are useful to assess in CF patients. Patients with CF also exhibit poor measures of growth compared to normal healthy children and these measures can be reported in a variety of ways.13 Anthropometrics such as height and weight are reported as either absolute values or as comparisons to healthy children. Growth charts summarize the height and weight of a large number of healthy children by plotting either height or weight on the y-axis compared to age on the x-axis.13 Assuming normal distribution, 95 percent of children will fall within two standard deviations of the mean height and weight for the age. Height and weight Z-scores (also called standard deviation scores or SDS) provide a relationship with the mean based on age and gender. The median Z-score for height and weight in patients with CF is −0.81 and −0.74, respectively, for both males and females,14 representing height and weight lower than the population norms. Percentile height or weight is another method to describe how a child compares to the norm.13 Approximately one-third of children with CF in the US are below the 10th percentile for height and for weight.14 Percentage weight-for-height may also be used to assess improvements in weight, while normalizing the patient’s height.13

All of these measures show that patients with CF are at a disadvantage in terms of height and weight, and treatments are aimed at getting these measures closer to that of healthy children.

## Recombinant Human Growth Hormone

Recombinant human growth hormone (rhGH) is an anabolic agent with a wide variety of actions. It is approved by the United States Food and Drug Administration (FDA) for the treatment of growth hormone deficiency, idiopathic short stature, Turner syndrome, Prader-Willi Syndrome, chronic renal insufficiency and for children who are small for gestational age.15 It has been investigated for the treatment of CF because of the decreased growth measures and increased energy expenditures in CF patients.9 In CF, there are multiple targets at which rhGH may provide benefit. First, it may improve linear growth, as seen in children with growth failure, including those with CF.5 rhGH may also decrease protein turnover, improve protein synthesis, and enhance bone mineralization.9,16 Because of the complications that may result from poor growth in patients with CF, rhGH is a worthwhile therapy to evaluate. The 2008 average wholesale price per milligram of rhGH (somatropin, various manufacturers) ranged from $36 to $65, so it would cost $16,848 to $30,420 annually to treat a 30 kg adolescent receiving a dose of 0.3mg/kg/week.16,17

## Scope and Key Questions

This is an evidence report prepared by the University of Connecticut/Hartford Hospital Evidence-based Practice Center (UCONN/HH EPC) examining the benefits and harms associated with using rhGH in patients with CF.

Key Question 1. In patients with CF, does treatment with rhGH as an adjuvant to usual care improve intermediate outcomes, including: pulmonary function; growth (height, weight, lean body mass, protein turnover); exercise tolerance; and bone mineralization, compared with usual care alone?

Key Question 2. In patients with CF, does treatment with rhGH as an adjuvant to usual care improve health outcomes, including: frequency of required intravenous antibiotic treatments; frequency of hospitalization; quality of life; bone fracture or development of osteoporosis/osteopenia; or mortality, compared with usual care alone?

Key Question 3. In patients with CF, what is the strength of evidence that intermediate outcomes of pulmonary function, growth, and bone mineralization are associated with improvements in health outcomes of quality of life, bone fracture or development of osteoporosis/osteopenia, or mortality?

Key Question 4. In patients with CF, what is the frequency of nonmalignant serious adverse effects resulting from treatment with rhGH in patients with CF? Adverse effects of interest include, but are not limited to: glucose intolerance, diabetes, and hypoglycemia.

Key Question 5. What is the risk of malignancy associated with rhGH use as determined by: (a) markers of cancer risk with rhGH (IGF-I increases over 100 ng/ml or IGFBP-3 decreases over 1000 ng/ml) from studies of rhGH in people with CF and by (b) assessment of evidence on cancer incidence from non-CF patients receiving modest doses of rhGH (0.2mg/kg/week to 0.6mg/kg/week) for disorders such as growth hormone deficiency (GHD) and idiopathic short stature (ISS)?

Key Question 6. In patients with CF, how is efficacy, effectiveness, safety or adverse events impacted by rhGH dose, therapy duration, baseline nutritional status, and concurrent medical therapies?

Key Question 7. In patients with CF, how do the efficacy, effectiveness, safety or adverse events of treatment with rhGH differ between subgroups of patients? Subgroup characteristics of interest include, but are not limited to: age (pre-pubertal, pubertal, post-pubertal); gender; baseline clinical status (height, weight, lean body mass, pulmonary function, exercise tolerance, nutritional status); and/or the nature, extent, and effectiveness of prior treatment.