# Additional Evidence Tables

Appendix Table F1 Trials reporting the relationship between pulmonary function and mortality

Study, Year | Population/Setting | Duration of Follow-up | Type of Analysis | Predictor | Univariate Relationship | Multivariate Relationship | Comments
Huang, 1987^1^ N=142 | Patients with CF seen at the clinic who had attained age 18 by the end of 1984. | Until death or Dec 1984 | Student’s t test or Chi-square test and Cox proportional hazards model | %FVC at baseline | ES NR NS | NR
Huang, 1987^1^ N=142 | Patients with CF seen at the clinic who had attained age 18 by the end of 1984. | Until death or Dec 1984 | Student’s t test or Chi-square test and Cox proportional hazards model | FEV_1_/FVC at baseline | ES NR NS | NR
Corey, 1988^2^ N=1033 | All patients with CF seen in established clinics for CF in Boston or Toronto in 1982. | 1 year | Student’s t test | %FEV_1_ at baseline in Boston | MD −40% p<0.05 | NR
Corey, 1988^2^ N=1033 | All patients with CF seen in established clinics for CF in Boston or Toronto in 1982. | 1 year | Student’s t test | %FEV_1_ at baseline in Toronto | MD −40% p<0.001 | NR
Kerem, 1992^3^ N=673 | Patients with CF followed between 1977 and 1989, whose pulmonary function was evaluated at least once before the end of 1987. | 2 years | Cox proportional hazards model | %FVC (10% decrease) | RR 1.9 (95%CI 1.8, 2.1) | RR 2.0 (95%CI 1.8, 2.2) | Univariate and Multivariate results reported as relative risk, likely reflect hazard ratio
Kerem, 1992^3^ N=673 | Patients with CF followed between 1977 and 1989, whose pulmonary function was evaluated at least once before the end of 1987. | 2 years | Cox proportional hazards model | %FEV_1_ (10% decrease) | RR 1.8 (95%CI 1.7, 2.0) | RR 2.0 (95%CI 1.9, 2.2) | Univariate and Multivariate results reported as relative risk, likely reflect hazard ratio
Nixon, 1992^4^ N=109 | Patients with CF aged 7 to 35, who underwent pulmonary function and exercise testing in the late 1970s. | 8 years | Cox proportional hazards model | %FEV_1_ ≤50 versus ≥65% | RR 3.7 (95%CI 1.8, 7.9) | RR 1.1 (95%CI 0.4, 2.7) | Univariate and Multivariate results reported as relative risk, likely reflect hazard ratio
Sharples, 1993^5^ N=67 | Adult patients with CF accepted for heart- lung transplantation between Jan 1, 1985 and Dec 31, 1990. | Until death or transplant by Dec 31, 1990 | Cox proportional hazards model | FEV_1_ at baseline | RR 0.28 (95%CI 0.08, 0.97) | NR | Univariate results reported as relative risk, likely reflects hazard ratio
Sharples, 1993^5^ N=67 | Adult patients with CF accepted for heart- lung transplantation between Jan 1, 1985 and Dec 31, 1990. | Until death or transplant by Dec 31, 1990 | Cox proportional hazards model | %FEV_1_ at baseline | RR 0.96 (95%CI 0.92, 1.00) | NR | Univariate results reported as relative risk, likely reflects hazard ratio
Sharples, 1993^5^ N=67 | Adult patients with CF accepted for heart- lung transplantation between Jan 1, 1985 and Dec 31, 1990. | Until death or transplant by Dec 31, 1990 | Cox proportional hazards model | FEV_1_/FVC at baseline | RR 1.00 (95%CI 0.98, 1.03) | NR | Univariate results reported as relative risk, likely reflects hazard ratio
Ciriaco, 1995^6^ N=67 | All patients with CF listed for lung transplantation between Jan 1990 and July 1993. | Until death or transplant by July 1993 | Student’s t test | FVC at baseline | MD 0 L (95%CI −0.48,0.48) | NR
Ciriaco, 1995^6^ N=67 | All patients with CF listed for lung transplantation between Jan 1990 and July 1993. | Until death or transplant by July 1993 | Student’s t test | %FVC at baseline | MD −2% (95%CI −5.35,9.35) | NR
Ciriaco, 1995^6^ N=67 | All patients with CF listed for lung transplantation between Jan 1990 and July 1993. | Until death or transplant by July 1993 | Student’s t test | FEV_1_ at baseline | MD −0.149 L (95%CI −0.08,0.38) | NR
Ciriaco, 1995^6^ N=67 | All patients with CF listed for lung transplantation between Jan 1990 and July 1993. | Until death or transplant by July 1993 | Student’s t test | %FEV_1_ at baseline | MD −5 % p<0.02 | NR
Corey, 1996^7^ N=3,795 | Patients from the Canadian Patient Data Registry, operated from the Canadian Cystic Fibrosis Foundation, between 1970 and 1989. | Until death or 1989 | Cox proportional hazards model | %FEV_1_ | HR 0.93 (95%CI 0.92, 0.94) | HR 0.93 (95%CI 0.92, 0.94)
Corey, 1997^8^ N=366 | All patients with CF born between 1960 and 1974 who had at least two recorded pulmonary function tests, and whose first test was performed before age 10. | 25 years | Mixed-model regression analysis | %FEV_1_ decline | NR | SS
Corey, 1997^8^ N=366 | All patients with CF born between 1960 and 1974 who had at least two recorded pulmonary function tests, and whose first test was performed before age 10. | 25 years | Mixed-model regression analysis | %FVC decline | NR | SS
Hayllar, 1997^9^ N=403 | Patients with CF seen between 1969 and 1987, followed until death or 1989. | Until death or 1989 | Cox proportional hazards model | %FVC at baseline | ES NR p<0.001 | RR 0.963 p<0.0001 | Multivariate results reported as relative risk, likely reflects hazard ratio
Hayllar, 1997^9^ N=403 | Patients with CF seen between 1969 and 1987, followed until death or 1989. | Until death or 1989 | Cox proportional hazards model | %FEV_1_ at baseline | ES NR p<0.001 | RR 0.943 p<0.0001 | Multivariate results reported as relative risk, likely reflects hazard ratio
Moorcroft, 1997^10^ N=92 | Patients with CF who underwent exercise testing between 1986 and 1989. | 5 years | Student’s t test | %FEV_1_ at baseline | MD −29.2% p<0.001 | ES NR SS
Rosenfeld, 1997^11^ N=21,047 | All patients with CF seen at a Cystic Fibrosis Foundation-accredited clinic between Jan 1988 and Dec 1992. | 2 years | Cox proportional hazards model | %FEV_1_ 60–80 versus >80 | HR 2.7 (95%CI 1.4, 5.5) | HR 1.8 (95%CI 0.7, 4.3)
Rosenfeld, 1997^11^ N=21,047 | All patients with CF seen at a Cystic Fibrosis Foundation-accredited clinic between Jan 1988 and Dec 1992. | 2 years | Cox proportional hazards model | %FEV_1_ 40–59 versus >80 | HR 14.0 (95%CI 7.8, 25.1) | HR 11.3 (95%CI 4.9, 26.3)
Rosenfeld, 1997^11^ N=21,047 | All patients with CF seen at a Cystic Fibrosis Foundation-accredited clinic between Jan 1988 and Dec 1992. | 2 years | Cox proportional hazards model | %FEV_1_ <40 versus >80 | HR 56.7 (95%CI 32.6, 98.5) | HR 27.5 (95%CI 11.2, 67.8)
Bell, 1998^12^ N=84 | All patients with CF seen for routine clinic appointment within 3 months of Feb 1994. | 4 years | Kaplan-Meier survival analysis and Cox proportional hazards model | %FEV_1_ at baseline | ES NR p<0.00001 | ES NR SS
Milla, 1998^13^ N=61 | All patients with CF followed up since 1975 in whom at least 3 years of follow-up data were available and who had FEV_1_ <30% predicted in more than three measurements within a single year and who did not have a subsequent value >30% predicted on more than one occasion. | Until death or time of analysis NR | Cox proportional hazards model | %FVC decline | MD 0.39% per year p=0.1 | ES NR NS
Milla, 1998^13^ N=61 | | Until death or time of analysis NR | Cox proportional hazards model | %FEV_1_ decline | MD 1.07% per year p=0.0001 | HR 1.3 p=0.0001
Venuta, 1998^14^ N=22 | Patients with CF evaluated for lung transplantation. | NR | Student’s t test | FVC at baseline | MD 0 L (95%CI −0.58,0.58) | NR
Venuta, 1998^14^ N=22 | Patients with CF evaluated for lung transplantation. | NR | Student’s t test | %FVC at baseline | MD −2% (95%CI −6.89,10.89) | NR
Venuta, 1998^14^ N=22 | Patients with CF evaluated for lung transplantation. | NR | Student’s t test | FEV_1_ at baseline | MD −0.09 L (95%CI −0.17,0.36) | NR
Venuta, 1998^14^ N=22 | Patients with CF evaluated for lung transplantation. | NR | Student’s t test | %FEV_1_ at baseline | MD 3.4% (95%CI −1.53,8.33) | NR
Robinson, 2000^15^ N=56 | Patients with CF between 7–18 years of age, followed at the Children’s Hospital in Boston, Massachusetts between 1980 and 1997. | 4 years | Fisher’s exact test | %FEV_1_ decline in 4 years preceding death | MD 6.1%/year p<0.01 | NR
Robinson, 2000^15^ N=56 | Patients with CF between 7–18 years of age, followed at the Children’s Hospital in Boston, Massachusetts between 1980 and 1997. | 4 years | Fisher’s exact test | %FEV_1_ decline in 2 years preceding death | MD 9.7%/year p<0.01 | NR
Robinson, 2000^15^ N=56 | Patients with CF between 7–18 years of age, followed at the Children’s Hospital in Boston, Massachusetts between 1980 and 1997. | 4 years | Fisher’s exact test | %FEV_1_ decline in 2 to 4 years preceding death | MD 4.25%/year p=0.22 | NR
Vizza, 2000^16^ N=146 | Patients with CF listed for lung transplantation at Barnes-Jewish Hospital between Jan 1, 1989 and May 12, 1998. | Until death or Feb 1999 | Student’s t test | FVC at baseline | MD −0.27 L p=0.006 | NR
Vizza, 2000^16^ N=146 | Patients with CF listed for lung transplantation at Barnes-Jewish Hospital between Jan 1, 1989 and May 12, 1998. | Until death or Feb 1999 | Student’s t test | %FVC at baseline | MD −4% p=0.031 | NR
Vizza, 2000^16^ N=146 | Patients with CF listed for lung transplantation at Barnes-Jewish Hospital between Jan 1, 1989 and May 12, 1998. | Until death or Feb 1999 | Student’s t test | FEV_1_ at baseline | MD −0.04 L p=0.251 | NR
Vizza, 2000^16^ N=146 | Patients with CF listed for lung transplantation at Barnes-Jewish Hospital between Jan 1, 1989 and May 12, 1998. | Until death or Feb 1999 | Student’s t test | %FEV_1_ at baseline | MD 0% p=0.823 | NR
Vizza, 2000^16^ N=146 | Patients with CF listed for lung transplantation at Barnes-Jewish Hospital between Jan 1, 1989 and May 12, 1998. | Until death or Feb 1999 | Student’s t test | FEV_1_/FVC at baseline | MD 0.04 p=0.011 | NR
Liou, 2001^17^ N=5820 | Patients in the Cystic Fibrosis Foundation Patient Registry who were alive in Jan 1993, and for whom follow-up data were available through Dec 1997. | 5 years | Cox proportional hazards model | %FEV_1_ | ES NR SS | OR 0.96 NR | Multivariate results reported as odds ratio, likely reflects hazard ratio
Sharma, 2001^18^ N=584 | Patients with CF attending to Royal Brompton Hospital between 1985 and 1996. | Until death or 1996 | Cox proportional hazards model | FEV_1_ at baseline | HR 0.999 (95%CI 0.998, 0.999) | NR
Sharma, 2001^18^ N=584 | Patients with CF attending to Royal Brompton Hospital between 1985 and 1996. | Until death or 1996 | Cox proportional hazards model | %FEV_1_ at baseline | HR 0.945 (95%CI 0.934, 0.956) | HR 0.953 (95%CI 0.931, 0.975)
Sharma, 2001^18^ N=584 | Patients with CF attending to Royal Brompton Hospital between 1985 and 1996. | Until death or 1996 | Cox proportional hazards model | %FEV_1_ ≤30 | HR 4.83 (95%CI 3.44, 6.78) | NR
Mayer-Hamblett, 2002^19^ N=14,572 | All patients in the Cystic Fibrosis Foundation National Patient Registry who were age 6 years or older on Dec 31, 1996, who had not previously undergone lung transplantation, and were seen at a CFF-accredited care center in 1996. | 2 years | Logistic regression | Mean FEV_1_ in 1996 | ES NR SS | OR 0.09 (95%CI 0.07, 0.11) | Multivariate results reported as odds ratio, likely reflects hazard ratio
Schaedel, 2002^20^ N=377 | Patients with CF attending one of four CF centers in Sweden, born before Jan 1,1993 and having undergone at least two lung function tests | Median 8.5 years | Mixed-model regression analysis | FEV_1_ decline | NR | SS
Stanchina, 2002^21^ N=44 | Patients with CF who underwent evaluation for lung transplantation between Nov 1990 and Jan 1999 at Massachusetts General Hospital. | Until death or Jan 1999 | Student’s t test and Cox proportional hazards model | FEV_1_ at baseline | MD −0.142 L (95%CI −0.05,0.33) | NR
Stanchina, 2002^21^ N=44 | Patients with CF who underwent evaluation for lung transplantation between Nov 1990 and Jan 1999 at Massachusetts General Hospital. | Until death or Jan 1999 | Student’s t test and Cox proportional hazards model | %FEV_1_ at baseline | MD 4.8% (95%CI −0.78,10.38) | NR
Vedam, 2004^22^ N=20 | All adult patients with CF admitted to the ICU at Royal Prince Alfred Hospital between 1988 and Apr 13, 2003. | Until death or 1 year following ICU discharge | Relative risk calculation | %FEV_1_ <24 upon admission | RR 3.68 (95%CI 1.11, 16.33) | NR | Univariate results reported as relative risk, likely reflects hazard ratio
Ellaffi, 2005^23^ N=69 | Adult patients with CF followed at the CF center at Cochin Hospital, that were admitted to the Pulmonary Department or ICU of the hospital for severe pulmonary exacerbations between Jan 1, 1997 and Jun 30, 2001. | 1 year | Cox proportional hazards model | %FEV_1_ in stable state prior to admission | HR 1.00 (95%CI 0.91,1.02) | NS
Ellaffi, 2005^23^ N=69 | | 1 year | Cox proportional hazards model | FEV_1_ decline | HR 0.70 (95%CI 0.49, 1.00) | NS
Pianosi, 2005^24^ N=28 | Children with CF seen at the CF clinic of the Winnipeg Health Sciences Center, old enough (≥7 years) to perform a progressive exercise test, at a scheduled clinic appointment when the patient was clinically stable, between 1991 and 1996. | Until death or Jan 2004 | Cox proportional hazards model | FEV_1_ decline | HR 0.959 (95%CI 0.928, 0.0991) | NR
Pianosi, 2005^24^ N=28 | | Until death or Jan 2004 | Cox proportional hazards model | FEV_1_ at last visit | HR 0.928 (95%CI 0.894, 0.968) | NR
Belkin, 2006^25^ N=346 | Adult and pediatric patients with CF listed for lung, heart-lung, or heart-lung-liver transplantation at the University of Pennsylvania, Stanford University Medical Center, Children’s Hospital of Philadelphia, Toronto General Hospital and the Hospital for Sick Children in Toronto between Jan 1990 and Dec 31, 2002. | Until death or Dec 31, 2002 | Cox proportional hazards model | %FEV_1_ (10% decrease) | HR 2.1 (95%CI 1.5, 3.0) | NS
Belkin, 2006^25^ N=346 | | Until death or Dec 31, 2002 | Cox proportional hazards model | %FVC (10% decrease) | HR 1.3 (95%CI 1.1, 1.6) | NS
Belkin, 2006^25^ N=346 | | Until death or Dec 31, 2002 | Cox proportional hazards model | FEV_1_ ≤30% at baseline | HR 3.8 (95%CI 2.0, 7.5) | HR 6.8 (95% CI 2.4, 19.3)
Texereau, 2006^26^ N=42 | Adult CF patients admitted to the ICU, who had never received a solid-organ transplant, between Jan 2000 and Jun 2003. | 1 year | Cox proportional hazards model | %FEV_1_, best value within six months preceding ICU admission | HR 0.97 (95%CI 0.93, 1.02) | NR
Texereau, 2006^26^ N=42 | Adult CF patients admitted to the ICU, who had never received a solid-organ transplant, between Jan 2000 and Jun 2003. | 1 year | Cox proportional hazards model | %FEV_1_ decline per year | HR 1.25 (95%CI 1.04, 1.52) | HR 1.47 (95%CI 1.18, 1.85)
Courtney, 2007^27^ N=183 | Adult patients (age ≥17 in 2000) from Belfast and Cork, between 1995 and 2005. | 10 years | Cox proportional hazards model | %FEV_1_ at baseline | MD −28.3% p<0.001 | ES NR p<0.0001
Rosenthal, 2008^28^ N=298 | Patients with CF born before 1993 with at least 4 annual lung function measurements in the patient database at the Royal Brompton Hospital in London, UK. | Until death or transplant by Jan 4, 2007 | Positive predictive value and sensitivity for mortality and Mann Whitney U test | FEV_1_ Z-score threshold −2 at age 8 | PPV 47 Sens 70 | NR
Rosenthal, 2008^28^ N=298 | Patients with CF born before 1993 with at least 4 annual lung function measurements in the patient database at the Royal Brompton Hospital in London, UK. | Until death or transplant by Jan 4, 2007 | Positive predictive value and sensitivity for mortality and Mann Whitney U test | FEV_1_ Z-score threshold −2 at age 9 | PPV 13 Sens 33 | NR
Rosenthal, 2008^28^ N=298 | Patients with CF born before 1993 with at least 4 annual lung function measurements in the patient database at the Royal Brompton Hospital in London, UK. | Until death or transplant by Jan 4, 2007 | Positive predictive value and sensitivity for mortality and Mann Whitney U test | FEV_1_ Z-score threshold −2 at age 10 | PPV 25 Sens 68 | NR
Rosenthal, 2008^28^ N=298 | Patients with CF born before 1993 with at least 4 annual lung function measurements in the patient database at the Royal Brompton Hospital in London, UK. | Until death or transplant by Jan 4, 2007 | Positive predictive value and sensitivity for mortality and Mann Whitney U test | FEV_1_ Z-score threshold −2 at age 11 | PPV 25 Sens 76 | NR
Rosenthal, 2008^28^ N=298 | Patients with CF born before 1993 with at least 4 annual lung function measurements in the patient database at the Royal Brompton Hospital in London, UK. | Until death or transplant by Jan 4, 2007 | Positive predictive value and sensitivity for mortality and Mann Whitney U test | FEV_1_ Z-score threshold −2 at age 12 | PPV 10 Sens 64 | NR
Rosenthal, 2008^28^ N=298 | Patients with CF born before 1993 with at least 4 annual lung function measurements in the patient database at the Royal Brompton Hospital in London, UK. | Until death or transplant by Jan 4, 2007 | Positive predictive value and sensitivity for mortality and Mann Whitney U test | FEV_1_ Z-score decline in 2 year prior to age 10 | MD 0.04 (95%CI −1.52,1.60) | NR
Rosenthal, 2008^28^ N=298 | Patients with CF born before 1993 with at least 4 annual lung function measurements in the patient database at the Royal Brompton Hospital in London, UK. | Until death or transplant by Jan 4, 2007 | Positive predictive value and sensitivity for mortality and Mann Whitney U test | FEV_1_ Z-score decline in 2 year prior to age 11 | MD 0.21 (95%CI −0.35,0.77) | NR
Rosenthal, 2008^28^ N=298 | Patients with CF born before 1993 with at least 4 annual lung function measurements in the patient database at the Royal Brompton Hospital in London, UK. | Until death or transplant by Jan 4, 2007 | Positive predictive value and sensitivity for mortality and Mann Whitney U test | FEV_1_ Z-score decline in 2 year prior to age 12 | MD 0.35 (95%CI −0.31,1.01) | NR

* Mean differences presented as values in patients who died versus those who survived (mean_died_ − mean_survived_)

Legend: CF=cystic fibrosis; CI=confidence interval; ES=effect size; FEV_1_=forced expiratory volume in 1 second; %FEV_1_=percent predicted forced expiratory volume in 1 second; FVC=forced vital capacity; %FVC=percent predicted forced vital capacity; HR=hazard ratio; MD=mean difference; NR=not reported; NS=not significant; OR=odds ratio; PPV=positive predictive value; RR=relative risk; Sens=sensitivity; SS=statistically significant

Appendix Table F2 Trials reporting the relationship between anthropometrics and mortality

Study, Year | Population/Setting | Duration of Follow-up | Type of Analysis | Predictor | Univariate Relationship | Multivariate Relationship | Comments
Kraemer, 1978^29^ N=117 | Children with CF seen between Jan 1956 and Jun 1976, divided into three groups based on symptoms at diagnosis. | Until death or age 10 | Chi-square test | Relative underweight | ES NR p<0.05 | NR
Huang, 1987^1^ N=142 | Patients with CF seen at the clinic who had attained age 18 by the end of 1984. | Until death or Dec 1984 | Student’s t test or Chi-square test and Cox proportional hazards model | Weight percentile | MD −10.8% p=0.0001 | NR
Huang, 1987^1^ N=142 | Patients with CF seen at the clinic who had attained age 18 by the end of 1984. | Until death or Dec 1984 | Student’s t test or Chi-square test and Cox proportional hazards model | Weight percentile <5 at age 18 | MD −39% p=0.0004 | ES NR p<0.0001
Corey, 1988^2^ N=1033 | All patients with CF seen in established clinics for CF in Boston or Toronto in 1982. | 1 year | Student’s t test | Height percentile at baseline in Boston | MD −1% (95%CI −12.29,10.29) | NR
Corey, 1988^2^ N=1033 | All patients with CF seen in established clinics for CF in Boston or Toronto in 1982. | 1 year | Student’s t test | Height percentile at baseline in Toronto | MD −10% P<0.05 | NR
Corey, 1988^2^ N=1033 | All patients with CF seen in established clinics for CF in Boston or Toronto in 1982. | 1 year | Student’s t test | Weight percentile at baseline in Boston | MD −25% P<0.001 | NR
Corey, 1988^2^ N=1033 | All patients with CF seen in established clinics for CF in Boston or Toronto in 1982. | 1 year | Student’s t test | Weight percentile at baseline in Toronto | MD −25% P<0.001 | NR
Kerem, 1992^3^ N=673 | Patients with CF followed between 1977 and 1989, whose pulmonary function was evaluated at least once before the end of 1987. | 2 years | Cox proportional hazards model | %Weight-for-height | RR 1.4 (95%CI 1.3, 1.5) | RR 1.4 (1.3, 1.5)
Nixon, 1992^4^ N=109 | Patients with CF aged 7 to 35, who underwent pulmonary function and exercise testing in the late 1970s. | 8 years | Cox proportional hazards model | BMI ≤16 versus ≥18.6 | RR 1.6 (95%CI 0.8, 3.1) | NR | Univariate results reported as relative risk, likely reflects relative risk
Sharples, 1993^5^ N=67 | Adult patients with CF accepted for heart-lung transplantation, between Jan 1, 1985 and Dec 31, 1990. | Until death or transplant by Dec 31, 1990 | Cox proportional hazards model | Weight-for-height | RR 0.96 (95%CI 0.92, 0.99) | NR | Univariate results reported as relative risk, likely reflects relative risk
Corey, 1996^7^ N=3795 | Patients from the Canadian Patient Data Registry, operated from the Canadian Cystic Fibrosis Foundation, between 1970 and 1989. | Until death or 1989 | Cox proportional hazards model | %Weight | HR 0.95 (95%CI 0.93, 0.96) | HR 0.99 (95%CI 0.98, 1.00)
Hayllar, 1997^9^ N=403 | Patients with CF seen between 1969 and 1987, followed until death or 1989. | Until death or 1989 | Cox proportional hazards model | Height | ES NR p<0.001 | RR 0.033 p<0.0001
Hayllar, 1997^9^ N=403 | Patients with CF seen between 1969 and 1987, followed until death or 1989. | Until death or 1989 | Cox proportional hazards model | % Weight | ES NR p<0.001 | NR
Moorcroft, 1997^10^ N=92 | Patients with CF who underwent exercise testing between 1986 and 1989. | 5 years | Student’s t test | BMI at baseline | MD −1.9 kg/m^2^ p=0.001 | ES NR NS
Rosenfeld, 1997^11^ N=21,047 | All patients with CF seen at a Cystic Fibrosis Foundation-accredited clinic between Jan 1988 and Dec 1992. | 2 years | Cox proportional hazards model | Height z-score −0.46 to −1.32 versus >−0.46 | HR 1.4 (95%CI 0.9, 2.1) | HR 1.1 (95%CI 0.6, 1.9)
Rosenfeld, 1997^11^ N=21,047 | All patients with CF seen at a Cystic Fibrosis Foundation-accredited clinic between Jan 1988 and Dec 1992. | 2 years | Cox proportional hazards model | Height z-score −1.33 to −2.21 versus >−0.46 | HR 1.6 (95%CI 1.1, 2.5) | HR 1.0 (95%CI 0.5, 1.9)
Rosenfeld, 1997^11^ N=21,047 | All patients with CF seen at a Cystic Fibrosis Foundation-accredited clinic between Jan 1988 and Dec 1992. | 2 years | Cox proportional hazards model | Height z-score −2.22 to −3.25 versus >−0.46 | HR 4.6 (95%CI 3.1, 6.7) | HR 1.9 (95%CI 0.9, 4.1)
Rosenfeld, 1997^11^ N=21,047 | All patients with CF seen at a Cystic Fibrosis Foundation-accredited clinic between Jan 1988 and Dec 1992. | 2 years | Cox proportional hazards model | Height Z-score ≤−3.26 versus >−0.46 | HR 8.8 (95%CI 5.9, 13.1) | HR 2.9 (95%CI 1.2, 7.0)
Rosenfeld, 1997^11^ N=21,047 | All patients with CF seen at a Cystic Fibrosis Foundation-accredited clinic between Jan 1988 and Dec 1992. | 2 years | Cox proportional hazards model | Weight Z-score −0.49 to −1.25 versus >−0.49 | HR 1.2 (95%CI 0.7, 2.1) | NR
Rosenfeld, 1997^11^ N=21,047 | All patients with CF seen at a Cystic Fibrosis Foundation-accredited clinic between Jan 1988 and Dec 1992. | 2 years | Cox proportional hazards model | Weight Z-score −1.26 to −1.98 versus >−0.49 | HR 2.8 (95%CI 1.7, 4.4) | NR
Rosenfeld, 1997^11^ N=21,047 | All patients with CF seen at a Cystic Fibrosis Foundation-accredited clinic between Jan 1988 and Dec 1992. | 2 years | Cox proportional hazards model | Weight Z-score −1.98 to −2.74 versus >−0.49 | HR 7.8 (95%CI 5.0, 12.2) | NR
Rosenfeld, 1997^11^ N=21,047 | All patients with CF seen at a Cystic Fibrosis Foundation-accredited clinic between Jan 1988 and Dec 1992. | 2 years | Cox proportional hazards model | Weight Z-score ≤−2.75 versus >−0.49 | HR 16.4 (95%CI 10.5, 25.6) | NR
Rosenfeld, 1997^11^ N=21,047 | All patients with CF seen at a Cystic Fibrosis Foundation-accredited clinic between Jan 1988 and Dec 1992. | 2 years | Cox proportional hazards model | %IBW 98 to 104.9 versus ≥105 | HR 0.9 (95%CI 0.6, 1.5) | NR
Rosenfeld, 1997^11^ N=21,047 | All patients with CF seen at a Cystic Fibrosis Foundation-accredited clinic between Jan 1988 and Dec 1992. | 2 years | Cox proportional hazards model | %IBW 90 to 97.9 versus ≥105 | HR 1.6 (95%CI 1.1, 2.3) | NR
Rosenfeld, 1997^11^ N=21,047 | All patients with CF seen at a Cystic Fibrosis Foundation-accredited clinic between Jan 1988 and Dec 1992. | 2 years | Cox proportional hazards model | %IBW 84 to 89.9 versus ≥105 | HR 3.2 (95%CI 2.2, 4.7) | NR
Rosenfeld, 1997^11^ N=21,047 | All patients with CF seen at a Cystic Fibrosis Foundation-accredited clinic between Jan 1988 and Dec 1992. | 2 years | Cox proportional hazards model | %IBW <84 versus ≥105 | HR 7.1 (95%CI 5.0, 10.2) | NR
Bell, 1998 N=81 | All patients with CF seen for routine clinic appointment within 3 months of Feb 1994. | 4 years | Kaplan-Meier survival analysis and Cox proportional hazards model | BMI at baseline | ES NR p=0.05 | ES NR SS
Venuta, 1998^14^ N=22 | Patients with CF evaluated for lung transplantation. | NR | Student’s t test | %Weight | MD −3.3% (95%CI −6.25,12.85) | NR
Vizza, 2000^16^ N=146 | Patients with CF listed for lung transplantation at Barnes-Jewish Hospital between Jan 1, 1989 and May 12, 1998. | Until death or Feb 1999 | Student’s t test | Height | MD −3 cm p=0.073 | NR
Vizza, 2000^16^ N=146 | Patients with CF listed for lung transplantation at Barnes-Jewish Hospital between Jan 1, 1989 and May 12, 1998. | Until death or Feb 1999 | Student’s t test | Weight | MD −2.4 kg p=0.200 | NR
Vizza, 2000^16^ N=146 | Patients with CF listed for lung transplantation at Barnes-Jewish Hospital between Jan 1, 1989 and May 12, 1998. | Until death or Feb 1999 | Student’s t test | %IBW | MD 1% p=0.685 | NR
Beker, 2001^30^ N=2273 | Patients from the Cystic Fibrosis Foundation registry born between 1980 and 1989, who had a minimum of four records, were alive at age 7, and contained a recorded height measurement at age 7 to 8. | Until death or 1993 | Cox proportional hazards model | Height-for-age below 5th percentile, males at age 5 | HR 2.9 (95%CI 1.23, 6.91) | NR
Beker, 2001^30^ N=2273 | Patients from the Cystic Fibrosis Foundation registry born between 1980 and 1989, who had a minimum of four records, were alive at age 7, and contained a recorded height measurement at age 7 to 8. | Until death or 1993 | Cox proportional hazards model | Height-for-age below 5th percentile, males at age 7 | HR 6.3 (95%CI 2.10, 18.87) | NR
Beker, 2001^30^ N=2273 | Patients from the Cystic Fibrosis Foundation registry born between 1980 and 1989, who had a minimum of four records, were alive at age 7, and contained a recorded height measurement at age 7 to 8. | Until death or 1993 | Cox proportional hazards model | Height-for-age below 5th percentile, females at age 5 | HR 4.3 (95%CI 2.54, 7.31) | NR
Beker, 2001^30^ N=2273 | Patients from the Cystic Fibrosis Foundation registry born between 1980 and 1989, who had a minimum of four records, were alive at age 7, and contained a recorded height measurement at age 7 to 8. | Until death or 1993 | Cox proportional hazards model | Height-for-age below 5th percentile, females at age 7 | HR 5.8 (95%CI 2.53, 13.11) | NR
Liou, 2001^17^ N=5820 | Patients in the Cystic Fibrosis Foundation Patient Registry who were alive in Jan 1993, and for whom follow-up data were available through Dec 1997. | 5 years | Cox proportional hazards model | Weight-for-age Z-score | ES NR SS | OR 0.75 NR | Univariate results reported as odds ratio, likely reflects hazard ratio
Sharma, 2001^18^ N=584 | Patients with CF attending to Royal Brompton Hospital between 1985 and 1996. | Until death or 1996 | Cox proportional hazards model | %IBW at baseline | HR 0.955 (95%CI 0.944, 0.967) | HR 0.968 (95%CI 0.947, 0.99)
Sharma, 2001^18^ N=584 | Patients with CF attending to Royal Brompton Hospital between 1985 and 1996. | Until death or 1996 | Cox proportional hazards model | %IBW ≤85 | HR 2.64 (95%CI 1.85, 3.75) | NR
Emerson, 2002^31^ N=3213 | Patients with CF who were age 1 to 5 years as of Dec 31, 1990, with a date of CF diagnosis before or during 1990, and seen at a CF clinic during 1990 and alive at the end of 1990 that were registered with the US Cystic Fibrosis Foundation National Patient Registry | 8 years | Kaplan-Meier estimate of survival and Cox regression model | Weight percentile ≤5 versus percentile >50 | NR | HR 3.9 (95%CI 2.1, 7.3)
Emerson, 2002^31^ N=3213 | | 8 years | Kaplan-Meier estimate of survival and Cox regression model | Weight percentile 5–15 versus percentile >50 | NR | HR 2.4 (95%CI 1.2, 4.8)
Emerson, 2002^31^ N=3213 | | 8 years | Kaplan-Meier estimate of survival and Cox regression model | Weight percentile 15–50 versus percentile >50 | NR | HR 1.5 (95%CI 0.8, 2.9)
Mayer-Hamblett, 2002^19^ N=14,572 | All patients in the Cystic Fibrosis Foundation National Patient Registry who were age 6 years or older on Dec 31, 1996, who had not previously undergone lung transplantation and were seen at a CFF-accredited care center in 1996. | 2 years | Logistic regression | Mean height in 1996 | ES NR SS | OR 1.04 (95%CI 1.03, 1.05)
Mayer-Hamblett, 2002^19^ N=14,572 | | 2 years | Logistic regression | Mean weight in 1996 | ES NR SS | ES NR NS
Oliveira, 2002^31^ N=127 | Patients with CF followed at the Hospital das Clinicas in Brazil between March 1977 and December 1997. | 12 years | Cox proportional hazards model | Height Z-score threshold at −1.29 | RR 4.06 p=0.06 | NR | Univariate and multivariate results reported as relative risk, likely reflects hazard ratio
Oliveira, 2002^31^ N=127 | Patients with CF followed at the Hospital das Clinicas in Brazil between March 1977 and December 1997. | 12 years | Cox proportional hazards model | Birth weight (kg) | RR 3.81 p=0.01 | RR 7 p<0.001 | Univariate and multivariate results reported as relative risk, likely reflects hazard ratio
Stanchina, 2002^21^ N=44 | Patients with CF who underwent evaluation for lung transplantation between Nov 1990 and Jan 1999 at Massachusetts General Hospital. | Until death or Jan 1999 | Student’s t test Cox proportional hazards model | Height at baseline | MD 0.6 in (95% CI −3.44,2.24) | NR
Stanchina, 2002^21^ N=44 | Patients with CF who underwent evaluation for lung transplantation between Nov 1990 and Jan 1999 at Massachusetts General Hospital. | Until death or Jan 1999 | Student’s t test Cox proportional hazards model | Weight | MD 6.5 lbs (95 CI −26.61,13.61) | NR
Stanchina, 2002^21^ N=44 | Patients with CF who underwent evaluation for lung transplantation between Nov 1990 and Jan 1999 at Massachusetts General Hospital. | Until death or Jan 1999 | Student’s t test Cox proportional hazards model | BMI | MD 1.26 kg/m^2^ (95%CI −3.91,1.39) | NR
Banjar, 2003^32^ N=190 | All CF patients referred to the CF clinic at the King Faisal Specialist Hospital and Research Center in Riyadh, Kingdom of Saudi Arabia during a 9 year period between Nov 1993 and Nov 2002. | 9 years | Student’s t test | Weight-for-height at baseline Height-for-age at baseline | MD −13 p=0.01 MD −1 p=0.8 | NR NR
Vedam, 2004^22^ N=20 | All adult patients with CF admitted to the ICU at Royal Prince Alfred Hospital between 1988 and Apr 13 2003. | Until death or 1 year following ICU discharge | Relative risk calculation | BMI <18 upon admission | RR 3.25 (95%CI 1.27, 3.25) | NR | Univariate results reported as relative risk, likely reflects hazard ratio
Ellaffi, 2005^23^ N=69 | Adult patients with CF followed at the CF center at Cochin Hospital, that were admitted to the Pulmonary Department or ICU of the hospital for severe pulmonary exacerbations between Jan 1, 1997 and Jun 30, 2001. | 1 year | Cox proportional hazards model | BMI on admission | HR 0.87 (95% CI 0.69, 1.11) | NR
Belkin, 2006^25^ N=346 | Adult and pediatric patients with CF listed for lung, heart-lung, or heart-lung-liver transplantation at the University of Pennsylvania, Stanford University Medical Center, Children’s Hospital of Philadelphia, Toronto General Hospital and the Hospital for Sick Children in Toronto between Jan 1990 and Dec 2002. | Until death or Dec 31, 2002 | Cox proportional hazards model, Student t test | Shortest height quartile | HR 1.4 (95% CI 0.9, 2.4) | NS
Belkin, 2006^25^ N=346 | | Until death or Dec 31, 2002 | Cox proportional hazards model, Student t test | BMI | HR 1.0 (95% CI 0.9, 1.1) | NS
Belkin, 2006^25^ N=346 | | Until death or Dec 31, 2002 | Cox proportional hazards model, Student t test | Height | MD −1 cm p=0.30 | NR
Texereau, 2006^26^ N=42 | Adult CF patients admitted to the ICU, who had never received a solid-organ transplant, between Jan 2000 and Jun 2003. | 1 year | Cox proportional hazards model | BMI | HR 0.95 (95%CI 0.80, 1.13) | NR
Courtney, 2007^27^ N=183 | Adult patients (age ≥ 17 in 2000) from Belfast and Cork, between 1995 and 2005. | 10 years | Cox proportional hazards model | BMI at baseline | MD −1.5 kg/m^2^ P=0.008 | ES NR P=0.31
Rosenthal, 2008^28^ N=298 | Patients with CF born before 1993 with at least four annual lung function measurements in the patient database at Royal Brompton Hospital in London, UK. | Until death or transplant by Jan 4, 2007 | Positive predictive value and sensitivity for mortality and Mann Whitney U test | BMI Z-score threshold −2 at age 8 | PPV 33 Sens 9 | NR
Rosenthal, 2008^28^ N=298 | Patients with CF born before 1993 with at least four annual lung function measurements in the patient database at Royal Brompton Hospital in London, UK. | Until death or transplant by Jan 4, 2007 | Positive predictive value and sensitivity for mortality and Mann Whitney U test | BMI Z-score threshold −2 at age 9 | PPV 0 Sens 0 | NR
Rosenthal, 2008^28^ N=298 | Patients with CF born before 1993 with at least four annual lung function measurements in the patient database at Royal Brompton Hospital in London, UK. | Until death or transplant by Jan 4, 2007 | Positive predictive value and sensitivity for mortality and Mann Whitney U test | BMI Z-score threshold −2 at age 10 | PPV 0 Sens 0 | NR
Rosenthal, 2008^28^ N=298 | Patients with CF born before 1993 with at least four annual lung function measurements in the patient database at Royal Brompton Hospital in London, UK. | Until death or transplant by Jan 4, 2007 | Positive predictive value and sensitivity for mortality and Mann Whitney U test | BMI Z-score threshold −2 at age 11 | PPV 7 Sens 6 | NR
Rosenthal, 2008^28^ N=298 | Patients with CF born before 1993 with at least four annual lung function measurements in the patient database at Royal Brompton Hospital in London, UK. | Until death or transplant by Jan 4, 2007 | Positive predictive value and sensitivity for mortality and Mann Whitney U test | BMI Z-score threshold −2 at age 12 | PPV 20 Sens 20 | NR
Rosenthal, 2008^28^ N=298 | Patients with CF born before 1993 with at least four annual lung function measurements in the patient database at Royal Brompton Hospital in London, UK. | Until death or transplant by Jan 4, 2007 | Positive predictive value and sensitivity for mortality and Mann Whitney U test | BMI Z-score decline in 2 year prior to age 10 | MD −0.05 (95%CI (−0.17,0.07) | NR
Rosenthal, 2008^28^ N=298 | Patients with CF born before 1993 with at least four annual lung function measurements in the patient database at Royal Brompton Hospital in London, UK. | Until death or transplant by Jan 4, 2007 | Positive predictive value and sensitivity for mortality and Mann Whitney U test | BMI Z-score decline in 2 year prior to age 11 | MD 0.53 (95%CI −0.25,1.31) | NR
Rosenthal, 2008^28^ N=298 | Patients with CF born before 1993 with at least four annual lung function measurements in the patient database at Royal Brompton Hospital in London, UK. | Until death or transplant by Jan 4, 2007 | Positive predictive value and sensitivity for mortality and Mann Whitney U test | BMI Z-score decline in 2 year prior to age 12 | MD 0.32 (95%CI −1.14, 0.50) | NR

* Mean differences presented as values in patients who died versus those who survived (mean_died_ − mean_survived_)

Legend: BMI=body mass index; CF=cystic fibrosis; CI=confidence interval; ES=effect size; HR=hazard ratio; IBW=ideal body weight; MD=mean difference; NR=not reported; NS=not significant; OR=odds ratio; PPV=positive predictive value; RR=relative risk; Sens=sensitivity; SS=statistically significant

Appendix Table F3 Trials reporting the relationship between exercise tolerance and mortality

Study, Year | Population/Setting | Duration of Follow-up | Type of Analysis | Predictor | Univariate Relationship | Multivariate Relationship | Comments
Nixon, 1992^4^ N=109 | Patients with CF aged 7 to 35, who underwent pulmonary function and exercise testing in the late 1970s. | 8 years | Cox proportional hazards model | Vo_2-peak_ ≤ 58 versus ≥ 82% | RR 6.4 (95%CI 2.6, 15.7) | RR 3.2 (95%CI 1.2, 8.6) | Univariate and Multivariate results reported as relative risk, likely reflects hazard ratio
Sharples, 1993^5^ N=67 | Adult patients with CF accepted for heart-lung transplantation, between Jan 1, 1985 and Dec 31, 1990. | Until death or transplant by Dec 31, 1990 | Cox proportional hazards model | 12 minute walk test (>540 meters) | RR 0.89 (95%CI 0.41,1.95) | NR | Univariate results reported as relative risk, likely reflects hazard ratio
Ciriaco, 1995^6^ N=67 | All patients with CF listed for lung transplantation. | Until death or transplant by July 1993 | Student’s t test | 6 minute walk test | MD −101.7 m NS | NR
Kadikar, 1997^33^ N=41 | Patients assessed for lung transplant at the Toronto Lung Transplant Program and either were accepted to the program or died during assessment were retrospectively reviewed between Jan 1991 and Jun 1995. | Until death or transplant by Jun 1995 | Student’s t test | 6 minute walk test | MD −137.4 m p=0.016 | NR
Moorcroft, 1997^10^ N=92 | Patients with CF who underwent exercise testing between 1986 and 1989. | 5 years | Student’s t test | Vo_2-peak_ % predicted | MD −12.9% p=0.022 | ES NR NS
Moorcroft, 1997^10^ N=92 | Patients with CF who underwent exercise testing between 1986 and 1989. | 5 years | Student’s t test | W_peak_ % predicted | MD −18.1% p=0.015 | ES NR NS
Moorcroft, 1997^10^ N=92 | Patients with CF who underwent exercise testing between 1986 and 1989. | 5 years | Student’s t test | VE/Vo_2_ | MD 6.3 p=0.002 | ES NR NS
Moorcroft, 1997^10^ N=92 | Patients with CF who underwent exercise testing between 1986 and 1989. | 5 years | Student’s t test | VE_peak_ | MD −8.1 L/min p=0.04 | ES NR NS
Venuta, 1998^14^ N=22 | Patients with CF evaluated for lung transplantation. | NR | Student’s t test | 6 minute walk test | MD −43 m (95% CI −53.23, 139.23) | NR
Vizza, 2000^16^ N=146 | Patients with CF listed for lung transplantation at Barnes-Jewish Hospital between Jan 1, 1989 and May 12, 1998. | Until death or Feb 1999 | Cox proportional hazards model | 6 minute walk test, 50 m increment | RR 0.73 (95%CI 0.62, 0.87) | RR 0.69 (95%CI 0.57, 0.84) | Univariate and Multivariate results reported as relative risk, likely reflects hazard ratio
Vizza, 2000^16^ N=146 | Patients with CF listed for lung transplantation at Barnes-Jewish Hospital between Jan 1, 1989 and May 12, 1998. | Until death or Feb 1999 | Cox proportional hazards model | 6 minute walk test, 5% increment | RR 0.82 (95%CI 0.72, 0.94) | NR | Univariate results reported as relative risk, likely reflects hazard ratio
Stanchina, 2002^21^ N=44 | Patients with CF who underwent evaluation for lung transplantation between Nov 1990 and Jan 1999 at Massachusetts General Hospital. | Until death or Jan 1999 | Student’s t test and Cox proportional hazards model | Vo_2-max_ initial | MD −0.171 L/min (95%CI −1.85,2.19) | NR
Pianosi, 2005^24^ N=28 | Children with CF seen at the CF clinic of the Winnipeg Health Sciences Center, old enough (≥ 7 years) to perform a progressive exercise test, at a scheduled clinic appointment when the patient was clinically stable, between 1991 and 1996. | Until death or Jan 2004 | Cox proportional hazards model | Vo_2-peak_ final | HR 0.953 (95%CI 0.865, 1.051) | NR
Pianosi, 2005^24^ N=28 | | Until death or Jan 2004 | Cox proportional hazards model | Vo_2-peak_ at last visit | HR 0.845 (95%CI 0.757, 0.944) | NR
Belkin, 2006^25^ N=346 | Adult and pediatric patients with CF listed for lung, heart-lung, or heart-lung-liver transplantation at the University of Pennsylvania, Stanford University Medical Center, Children’s Hospital of Philadelphia, Toronto General Hospital and the Hospital for Sick Children in Toronto between Jan 1990 and Dec 31, 2002. | Until death or Dec 31, 2002 | Cox proportional hazards model | 6 minute walk distance, ft | HR 1.0 (95%CI 0.99, 1.0) | NR

* Mean differences presented as values in patients who died versus those who survived (mean_died_ − mean_survived_)

Legend: CF=cystic fibrosis; CI=confidence interval; ES=effect size; HR=hazard ratio; MD=mean difference; NR=not reported; NS=not significant; RR=relative risk; SS=statistically significant; VE_peak_=peak ventilation in one minute; Vo_2-peak_=peak oxygen uptake; W_peak_=peak work rate

Appendix Table F4 Trials reporting the relationship between pulmonary function and health-related quality of life

Study, Year | Population/Setting | Duration of Follow-up | Type of Analysis | Outcome | Predictor | Univariate Relationship | Multivariate Relationship
Orenstein, 1989^34^ N=44 | Patients with CF, aged 7 to 36 years, seen at the Pittsburgh Cystic Fibrosis Center | Cross-sectional | Pearson product moment correlation analysis | QWB | FEV_1_ | r=0.5518 p<0.0001 | NR
Czyzewski, 1994^35^ N=54 | Patients with CF from two metropolitan CF centers, younger than age 18 years that read and spoke English. | Cross-sectional | Pearson product moment correlation analysis | QWB | %FEV_1_ | r=−0.07 NS | NR
Czyzewski, 1994^35^ N=54 | Patients with CF from two metropolitan CF centers, younger than age 18 years that read and spoke English. | Cross-sectional | Pearson product moment correlation analysis | QWB | %FVC | r=0.00 NS | NR
Congleton, 1996^36^ N=240 | Patients with CF aged at least 16 years that attended the CF clinic at the National Heart and Lung Institute in Sydney, Australia for at least two years. | Cross-sectional | Spearman’s rank correlation coefficient | NHP Energy Subscore | %FEV_1_ | r=−0.43 p<0.0001 | NR
Congleton, 1996^36^ N=240 | Patients with CF aged at least 16 years that attended the CF clinic at the National Heart and Lung Institute in Sydney, Australia for at least two years. | Cross-sectional | Spearman’s rank correlation coefficient | NHP Pain Subscore | %FEV_1_ | r=−0.43 p<0.0001 | NR
Congleton, 1996^36^ N=240 | Patients with CF aged at least 16 years that attended the CF clinic at the National Heart and Lung Institute in Sydney, Australia for at least two years. | Cross-sectional | Spearman’s rank correlation coefficient | NHP Emotion Subscore | %FEV_1_ | r=−0.15 p<0.05 | NR
Congleton, 1996^36^ N=240 | Patients with CF aged at least 16 years that attended the CF clinic at the National Heart and Lung Institute in Sydney, Australia for at least two years. | Cross-sectional | Spearman’s rank correlation coefficient | NHP Sleep Subscore | %FEV_1_ | r=−0.3 p<0.0001 | NR
Congleton, 1996^36^ N=240 | Patients with CF aged at least 16 years that attended the CF clinic at the National Heart and Lung Institute in Sydney, Australia for at least two years. | Cross-sectional | Spearman’s rank correlation coefficient | NHP Social isolation Subscore | %FEV_1_ | r=−0.17 p<0.01 | NR
Congleton, 1996^36^ N=240 | Patients with CF aged at least 16 years that attended the CF clinic at the National Heart and Lung Institute in Sydney, Australia for at least two years. | Cross-sectional | Spearman’s rank correlation coefficient | NHP Physical mobility Subscore | %FEV_1_ | r=−0.51 p<0.0001 | NR
de Jong, 1997^37^ N=15 | Clinically stable patients with CF, aged 16 to 40 years. | Cross-sectional | Spearman’s rank correlation coefficient | SIP Overall Score | %FEV_1_ | r=−0.33 NS | NR
de Jong, 1997^37^ N=15 | Clinically stable patients with CF, aged 16 to 40 years. | Cross-sectional | Spearman’s rank correlation coefficient | SIP Physical Subscore | %FEV_1_ | r=−0.40 NS | NR
de Jong, 1997^37^ N=15 | Clinically stable patients with CF, aged 16 to 40 years. | Cross-sectional | Spearman’s rank correlation coefficient | SIP Psychosocial Subscore | %FEV_1_ | r=0.05 NS | NR
Staab, 1998^38^ N=89 | Adolescent and adult patients (n=89) attending four outpatient clinics in Germany. | Cross-Sectional | Multiple regression analyses | Alltagsleben (Every Day Life) | FEV_1_ | Model 1 (n=83) r=0.31 p<0.01 Model 2 (n=84) r=0.36 p<0.001 | Model 1 (n=83) β=0.12 NS Model 2 (n=84) β=0.24 p<0.05
Johnson, 2000^39^ N=39 at initial survey N=32 at 1 year | All patients with CF over age 18 years at the University of Alberta Hospital CF clinic. | Cross-sectional, with one 1 follow-up survey | Spearman correlations and multivariate regression models | SF-36 PCS | %FEV_1_ | Spearman’s p=0.396 p=0.025 | NR
Johnson, 2000^39^ N=39 at initial survey N=32 at 1 year | All patients with CF over age 18 years at the University of Alberta Hospital CF clinic. | Cross-sectional, with one 1 follow-up survey | Spearman correlations and multivariate regression models | SF-36 MCS | %FEV_1_ | ES NR NS | NR
Johnson, 2000^39^ N=39 at initial survey N=32 at 1 year | All patients with CF over age 18 years at the University of Alberta Hospital CF clinic. | Cross-sectional, with one 1 follow-up survey | Spearman correlations and multivariate regression models | EQ-5D VAS | %FEV_1_ | Spearman’s p=0.427 p=0.017 | NR
Johnson, 2000^39^ N=39 at initial survey N=32 at 1 year | All patients with CF over age 18 years at the University of Alberta Hospital CF clinic. | Cross-sectional, with one 1 follow-up survey | Spearman correlations and multivariate regression models | EQ-5D VAS after one year | %FEV_1_ | NR | β=+0.00 p=0.005
Abbott, 2001^40^ N=84 | English patients (n=58) with CF attending two outpatient clinics who were aged between 14 and 18 years. German patients (n=26) with CF attending outpatient clinics aged between 13 and 17 years. | Cross-sectional | Pearson’s correlation coefficient | SF-36 Physical functioning subscore | %FEV_1_ | English Patients r=0.39 p<0.003 German Patients r=0.43 p<0.03 | NR
Abbott, 2001^40^ N=84 | English patients (n=58) with CF attending two outpatient clinics who were aged between 14 and 18 years. German patients (n=26) with CF attending outpatient clinics aged between 13 and 17 years. | Cross-sectional | Pearson’s correlation coefficient | SF-36 Physical role limitation subscore | %FEV_1_ | ES NR NS | NR
Abbott, 2001^40^ N=84 | English patients (n=58) with CF attending two outpatient clinics who were aged between 14 and 18 years. German patients (n=26) with CF attending outpatient clinics aged between 13 and 17 years. | Cross-sectional | Pearson’s correlation coefficient | SF-36 Social functioning subscore | %FEV_1_ | ES NR NS | NR
Abbott, 2001^40^ N=84 | English patients (n=58) with CF attending two outpatient clinics who were aged between 14 and 18 years. German patients (n=26) with CF attending outpatient clinics aged between 13 and 17 years. | Cross-sectional | Pearson’s correlation coefficient | SF-36 Mental health subscore | %FEV_1_ | ES NR NS | NR
Abbott, 2001^40^ N=84 | English patients (n=58) with CF attending two outpatient clinics who were aged between 14 and 18 years. German patients (n=26) with CF attending outpatient clinics aged between 13 and 17 years. | Cross-sectional | Pearson’s correlation coefficient | SF-36 Mental role limitation subscore | %FEV_1_ | ES NR NS | NR
Abbott, 2001^40^ N=84 | English patients (n=58) with CF attending two outpatient clinics who were aged between 14 and 18 years. German patients (n=26) with CF attending outpatient clinics aged between 13 and 17 years. | Cross-sectional | Pearson’s correlation coefficient | SF-36 Energy and vitality subscore | %FEV_1_ | ES NR NS | NR
Abbott, 2001^40^ N=84 | English patients (n=58) with CF attending two outpatient clinics who were aged between 14 and 18 years. German patients (n=26) with CF attending outpatient clinics aged between 13 and 17 years. | Cross-sectional | Pearson’s correlation coefficient | SF-36 General health perceptions subscore | %FEV_1_ | ES NR NR | NR
Abbott, 2001^40^ N=84 | English patients (n=58) with CF attending two outpatient clinics who were aged between 14 and 18 years. German patients (n=26) with CF attending outpatient clinics aged between 13 and 17 years. | Cross-sectional | Pearson’s correlation coefficient | SF-36 Changes in health subscore | %FEV_1_ | ES NR NS | NR
Powers, 2001^41^ N=24 | Adolescents with CF aged 11 to 18 years at two CF clinics in Massachusetts, USA, who spoke English. | Cross-sectional | Pearson’s correlation coefficient | CHQ Physical function subscore | %FEV_1_ | r=0.37 NS | NR
Powers, 2001^41^ N=24 | Adolescents with CF aged 11 to 18 years at two CF clinics in Massachusetts, USA, who spoke English. | Cross-sectional | Pearson’s correlation coefficient | CHQ Role/social limitations – physical subscore | %FEV_1_ | r=0.47 p ≤0.05 | NR
Powers, 2001^41^ N=24 | Adolescents with CF aged 11 to 18 years at two CF clinics in Massachusetts, USA, who spoke English. | Cross-sectional | Pearson’s correlation coefficient | CHQ General health perceptions subscore | %FEV_1_ | r=0.73 p ≤0.001 | NR
Powers, 2001^41^ N=24 | Adolescents with CF aged 11 to 18 years at two CF clinics in Massachusetts, USA, who spoke English. | Cross-sectional | Pearson’s correlation coefficient | CHQ Bodily pain/discomfort subscore | %FEV_1_ | r=0.42 p ≤0.05 | NR
Powers, 2001^41^ N=24 | Adolescents with CF aged 11 to 18 years at two CF clinics in Massachusetts, USA, who spoke English. | Cross-sectional | Pearson’s correlation coefficient | CHQ Role/social limitations – emotional subscore | %FEV_1_ | r=0.39 NS | NR
Powers, 2001^41^ N=24 | Adolescents with CF aged 11 to 18 years at two CF clinics in Massachusetts, USA, who spoke English. | Cross-sectional | Pearson’s correlation coefficient | CHQ Role/social limitations – behavioral subscore | %FEV_1_ | r=−0.21 NS | NR
Powers, 2001^41^ N=24 | Adolescents with CF aged 11 to 18 years at two CF clinics in Massachusetts, USA, who spoke English. | Cross-sectional | Pearson’s correlation coefficient | CHQ Self-esteem subscore | %FEV_1_ | r=0.24 NS | NR
Powers, 2001^41^ N=24 | Adolescents with CF aged 11 to 18 years at two CF clinics in Massachusetts, USA, who spoke English. | Cross-sectional | Pearson’s correlation coefficient | CHQ Mental health subscore | %FEV_1_ | r=0.27 NS | NR
Powers, 2001^41^ N=24 | Adolescents with CF aged 11 to 18 years at two CF clinics in Massachusetts, USA, who spoke English. | Cross-sectional | Pearson’s correlation coefficient | CHQ General behavior subscore | %FEV_1_ | r=−0.04 NS | NR
Powers, 2001^41^ N=24 | Adolescents with CF aged 11 to 18 years at two CF clinics in Massachusetts, USA, who spoke English. | Cross-sectional | Pearson’s correlation coefficient | CHQ Family activities subscore | %FEV_1_ | r=0.34 NS | NR
Gee, 2003 and 2005^42,43^ N=223 | Patients with CF attending regional adult CF centers. | Cross-sectional | Pearson’s correlation coefficient Multiple regression analysis | CFQoL Physical functioning subscore | FEV_1_ | Males r=0.50 p=0.001 Females r=0.25 p=0.005 | β=0.20 (95%CI 0.11, 0.29)
Gee, 2003 and 2005^42,43^ N=223 | Patients with CF attending regional adult CF centers. | Cross-sectional | Pearson’s correlation coefficient Multiple regression analysis | CFQoL Social functioning subscore | FEV_1_ | Males r=0.26 p=0.007 Females r=NS p=NS | β=0.12 (95%CI 0.004, 0.25)
Gee, 2003 and 2005^42,43^ N=223 | Patients with CF attending regional adult CF centers. | Cross-sectional | Pearson’s correlation coefficient Multiple regression analysis | CFQoL Treatment issues subscore | %FEV_1_ | Males r=0.27 p=0.005 Females r=0.17 p=0.05 | β=0.17 (95%CI 0.03, 0.32)
Gee, 2003 and 2005^42,43^ N=223 | Patients with CF attending regional adult CF centers. | Cross-sectional | Pearson’s correlation coefficient Multiple regression analysis | CFQoL Chest symptoms subscore | %FEV_1_ | Males r=0.38 p=0.001 Females r=0.21 p=0.02 | β=0.29 (95%CI 0.14, 0.43)
Gee, 2003 and 2005^42,43^ N=223 | Patients with CF attending regional adult CF centers. | Cross-sectional | Pearson’s correlation coefficient Multiple regression analysis | CFQoL Emotional functioning subscore | %FEV_1_ | Males r=0.27 p=0.005 Females r=0.60 p=0.001 | β=0.14 (95%CI 0.02, 0.24)
Gee, 2003 and 2005^42,43^ N=223 | Patients with CF attending regional adult CF centers. | Cross-sectional | Pearson’s correlation coefficient Multiple regression analysis | CFQoL Concerns for the future subscore | %FEV_1_ | Males r=0.22 p=0.02 Females r=NS p=NS | β=0.15 (95%CI 0.01, 0.28)
Gee, 2003 and 2005^42,43^ N=223 | Patients with CF attending regional adult CF centers. | Cross-sectional | Pearson’s correlation coefficient Multiple regression analysis | CFQoL Interpersonal relationships subscore | %FEV_1_ | Males r=NS p=NS Females r=0.28 p=0.002 | β=0.18 (95%CI 0.06, 0.30)
Gee, 2003 and 2005^42,43^ N=223 | Patients with CF attending regional adult CF centers. | Cross-sectional | Pearson’s correlation coefficient Multiple regression analysis | CFQoL Body image subscore | %FEV_1_ | Males r=0.41 p=0.001 Females r=0.25 p=0.005 | β=0.10 (95%CI −0.05, 0.23)
Gee, 2003 and 2005^42,43^ N=223 | Patients with CF attending regional adult CF centers. | Cross-sectional | Pearson’s correlation coefficient Multiple regression analysis | CFQoL Career concerns subscore | %FEV_1_ | Males r=0.22 p=0.02 Females r=0.18 p=0.03 | β=0.11 (95%CI −0.05, 0.30)
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross-sectional | Spearman’s rank correlation coefficient | CHQ Physical function subscore | FEV_1_ | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross-sectional | Spearman’s rank correlation coefficient | CHQ Role/social limitations – physical subscore | FEV_1_ | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross-sectional | Spearman’s rank correlation coefficient | CHQ General health perceptions subscore | FEV_1_ | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross-sectional | Spearman’s rank correlation coefficient | CHQ Bodily pain/discomfort subscore | FEV_1_ | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross-sectional | Spearman’s rank correlation coefficient | CHQ Role/social limitations – emotional subscore | FEV_1_ | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross-sectional | Spearman’s rank correlation coefficient | CHQ Role/social limitations – behavioral subscore | FEV_1_ | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross-sectional | Spearman’s rank correlation coefficient | CHQ Self-esteem subscore | FEV_1_ | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross-sectional | Spearman’s rank correlation coefficient | CHQ Mental health subscore | FEV_1_ | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross-sectional | Spearman’s rank correlation coefficient | CHQ General behavior subscore | FEV_1_ | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross-sectional | Spearman’s rank correlation coefficient | CHQ Family activities subscore | FEV_1_ | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross-sectional | Spearman’s rank correlation coefficient | CHQ Family cohesion subscore | FEV_1_ | r=0.37 p=0.05 | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross-sectional | Spearman’s rank correlation coefficient | CHQ Change in health subscore | FEV_1_ | ES NR NS | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Physical domain | %FEV_1_ | r=0.42 p<0.01 | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Role domain | %FEV_1_ | r=0.28 p<0.01 | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Vitality domain | %FEV_1_ | r=0.26 p<0.01 | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Emotion domain | %FEV_1_ | r=0.28 p<0.01 | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Social domain | %FEV_1_ | r=0.33 p<0.01 | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Body image domain | %FEV_1_ | r=0.38 p<0.01 | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Eating domain | %FEV_1_ | r=0.23 p<0.01 | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Treatment burden domain | %FEV_1_ | r=0.11 NS | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Health perceptions domain | %FEV_1_ | r=0.45 p<0.01 | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Respiratory domain | %FEV_1_ | r=0.39 p<0.01 | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Digestive domain | %FEV_1_ | r=0.03 NS | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Weight domain | %FEV_1_ | r=0.35 p<0.01 | NR
Goldbeck, 2007^46^ N=108 | Adolescent and adult patients with CF, at least age 15 years. | 18 months | Multiple regression analysis | Questions on Life Satisfaction | %FEV_1_ at second visit | NR | ES NR NS
Goldbeck, 2007^46^ N=108 | Adolescent and adult patients with CF, at least age 15 years. | 18 months | Multiple regression analysis | Questions on Life Satisfaction | Change in %FEV_1_ between two visits | NR | ES NR NS
Riekert, 2007^47^ N=76 | Adults with CF seen at clinic between April 2002 and Nov 2003. | Cross- sectional | Spearman correlation coefficient | CFQ Physical domain | %FEV_1_ | r=0.57 p<0.001 | NR
Riekert, 2007^47^ N=76 | Adults with CF seen at clinic between April 2002 and Nov 2003. | Cross- sectional | Spearman correlation coefficient | CFQ Respiratory domain | %FEV_1_ | r=0.39 p<0.001 | NR
Riekert, 2007^47^ N=76 | Adults with CF seen at clinic between April 2002 and Nov 2003. | Cross- sectional | Spearman correlation coefficient | CFQ Vitality domain | %FEV_1_ | r=0.33 p<0.01 | NR
Riekert, 2007^47^ N=76 | Adults with CF seen at clinic between April 2002 and Nov 2003. | Cross- sectional | Spearman correlation coefficient | CFQ Social domain | %FEV_1_ | r=0.38 p<0.001 | NR
Riekert, 2007^47^ N=76 | Adults with CF seen at clinic between April 2002 and Nov 2003. | Cross- sectional | Spearman correlation coefficient | CFQ Health perceptions domain | %FEV_1_ | r=0.51 p<0.001 | NR
Riekert, 2007^47^ N=76 | Adults with CF seen at clinic between April 2002 and Nov 2003. | Cross- sectional | Spearman correlation coefficient | CFQ Treatment domain | %FEV_1_ | r=0.32 p<0.01 | NR
Riekert, 2007^47^ N=76 | Adults with CF seen at clinic between April 2002 and Nov 2003. | Cross- sectional | Spearman correlation coefficient | CFQ Role domain | %FEV_1_ | r=0.35 p<0.01 | NR
Riekert, 2007^47^ N=76 | Adults with CF seen at clinic between April 2002 and Nov 2003. | Cross- sectional | Spearman correlation coefficient | CFQ Emotion domain | %FEV_1_ | r=0.20 NS | NR
Riekert, 2007^47^ N=76 | Adults with CF seen at clinic between April 2002 and Nov 2003. | Cross- sectional | Spearman correlation coefficient | CFQ Body image domain | %FEV_1_ | r=0.38 p<0.001 | NR
Riekert, 2007^47^ N=76 | Adults with CF seen at clinic between April 2002 and Nov 2003. | Cross- sectional | Spearman correlation coefficient | CFQ Eating domain | %FEV_1_ | r=0.33 p<0.01 | NR
Riekert, 2007^47^ N=76 | Adults with CF seen at clinic between April 2002 and Nov 2003. | Cross- sectional | Spearman correlation coefficient | CFQ Digestion domain | %FEV_1_ | r=0.01 NS | NR
Riekert, 2007^47^ N=76 | Adults with CF seen at clinic between April 2002 and Nov 2003. | Cross- sectional | Spearman correlation coefficient | CFQ Weight domain | %FEV_1_ | r=0.41 p<0.001 | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross- sectional | Pearson correlation | CFQ Physical domain | %FEV_1_ | r=0.27 p<0.05 | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross- sectional | Pearson correlation | CFQ Respiratory domain | %FEV_1_ | NR | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross- sectional | Pearson correlation | CFQ Vitality domain | %FEV_1_ | NR | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross- sectional | Pearson correlation | CFQ Social domain | %FEV_1_ | NR | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross- sectional | Pearson correlation | CFQ Health perceptions domain | %FEV_1_ | r=0.38 p<0.05 | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross- sectional | Pearson correlation | CFQ Treatment domain | %FEV_1_ | NR | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross- sectional | Pearson correlation | CFQ Role domain | %FEV_1_ | NR | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross- sectional | Pearson correlation | CFQ Emotion domain | %FEV_1_ | NR | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross- sectional | Pearson correlation | CFQ Body image domain | %FEV_1_ | NR | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross- sectional | Pearson correlation | CFQ Eating domain | %FEV_1_ | NR | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross- sectional | Pearson correlation | CFQ Digestion domain | %FEV_1_ | NR | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross- sectional | Pearson correlation | CFQ Weight domain | %FEV_1_ | NR | NR

Legend: CF=cystic fibrosis; CFQ=Cystic Fibrosis Questionnaire; CFQoL=Cystic Fibrosis Quality of Life questionnaire; CHQ=Child Health Questionnaire; CI=confidence interval; ES=effect size; EQ-5D=EuroQol 5D; FEV_1_=forced expiratory volume in 1 second; %FEV_1_=percent predicted forced expiratory volume in 1 second; FVC=forced vital capacity; %FVC=percent predicted forced vital capacity; MCS=mental composite score; NHP=Nottingham Health Profile; NR=not reported; NS=not significant; PCS=physical composite score; QWB=Quality of Well-Being Scale; SF-36=Medical Outcomes Short-Form 36; SIP=Sickness Impact Profile; SS=statistically significant; VAS=visual analog scale

Appendix Table F5 Trials reporting the relationship between anthropometrics and health-related quality of life

Study, Year | Population/Setting | Duration of Follow-up | Type of Analysis | Outcome | Predictor | Univariate Relationship | Multivariate Relationship
Congleton, 1996^36^ N=240 | Patients with CF aged at least 16 years that attended the CF clinic at the National Heart and Lung Institute in Sydney, Australia for at least 2 years. | Cross- sectional | Spearman’s rank correlation coefficient | NHP Energy Subscore | BMI | r=−0.20 p<0.001 | NR
Congleton, 1996^36^ N=240 | Patients with CF aged at least 16 years that attended the CF clinic at the National Heart and Lung Institute in Sydney, Australia for at least 2 years. | Cross- sectional | Spearman’s rank correlation coefficient | NHP Pain Subscore | BMI | r=−0.02 NS | NR
Congleton, 1996^36^ N=240 | Patients with CF aged at least 16 years that attended the CF clinic at the National Heart and Lung Institute in Sydney, Australia for at least 2 years. | Cross- sectional | Spearman’s rank correlation coefficient | NHP Emotion Subscore | BMI | r=−0.07 NS | NR
Congleton, 1996^36^ N=240 | Patients with CF aged at least 16 years that attended the CF clinic at the National Heart and Lung Institute in Sydney, Australia for at least 2 years. | Cross- sectional | Spearman’s rank correlation coefficient | NHP Sleep Subscore | BMI | r=−0.15 p<0.05 | NR
Congleton, 1996^36^ N=240 | Patients with CF aged at least 16 years that attended the CF clinic at the National Heart and Lung Institute in Sydney, Australia for at least 2 years. | Cross- sectional | Spearman’s rank correlation coefficient | NHP Social isolation Subscore | BMI | r=−0.04 NS | NR
Congleton, 1996^36^ N=240 | Patients with CF aged at least 16 years that attended the CF clinic at the National Heart and Lung Institute in Sydney, Australia for at least 2 years. | Cross- sectional | Spearman’s rank correlation coefficient | NHP Physical mobility Subscore | BMI | r=−0.30 p<0.0001 | NR
Staab, 1998^38^ N=89 | Adolescent and adult patients (n=89) attending four outpatient clinics in Germany. | Cross- Sectional | Multiple regression analyses | Alltagsleben (Every Day Life) | %IBW | Model 1 (n=83) r=0.11 NS Model 2 (n=84) r=0.10 NS | Model 1 (n=83) β=0.05 NS Model 2 (n=84) β=−0.11 NS
Johnson, 2000^39^ N=39 at initial survey N=32 at 1 year | All patients with CF over age 18 years at the University of Alberta Hospital CF clinic. | Cross- sectional, with one 1 follow- up survey | Spearman correlations and multivariate regression models | SF-36 PCS | BMI | ES NR NS | NR
Johnson, 2000^39^ N=39 at initial survey N=32 at 1 year | All patients with CF over age 18 years at the University of Alberta Hospital CF clinic. | Cross- sectional, with one 1 follow- up survey | Spearman correlations and multivariate regression models | SF-36 MCS | BMI | ES NR NS | NR
Johnson, 2000^39^ N=39 at initial survey N=32 at 1 year | All patients with CF over age 18 years at the University of Alberta Hospital CF clinic. | Cross- sectional, with one 1 follow- up survey | Spearman correlations and multivariate regression models | EQ-5D VAS | BMI | ES NR NS | NR
Johnson, 2000^39^ N=39 at initial survey N=32 at 1 year | All patients with CF over age 18 years at the University of Alberta Hospital CF clinic. | Cross- sectional, with one 1 follow- up survey | Spearman correlations and multivariate regression models | EQ-5D VAS after one year | BMI | ES NR NR | β=−0.002 p=0.005
Abbott, 2001^40^ N=84 | English patients (n=58) with CF attending two outpatient clinics who were aged between 14 and 18 years. German patients (n=26) with CF attending outpatient clinics aged between 13 and 17 years. | Cross- sectional | Pearson’s correlation coefficient | SF-36 Physical functioning subscore | BMI | ES NR NS | NR
Abbott, 2001^40^ N=84 | English patients (n=58) with CF attending two outpatient clinics who were aged between 14 and 18 years. German patients (n=26) with CF attending outpatient clinics aged between 13 and 17 years. | Cross- sectional | Pearson’s correlation coefficient | SF-36 Physical role limitation subscore | BMI | ES NR NS | NR
Abbott, 2001^40^ N=84 | English patients (n=58) with CF attending two outpatient clinics who were aged between 14 and 18 years. German patients (n=26) with CF attending outpatient clinics aged between 13 and 17 years. | Cross- sectional | Pearson’s correlation coefficient | SF-36 Social functioning subscore | BMI | ES NR NS | NR
Abbott, 2001^40^ N=84 | English patients (n=58) with CF attending two outpatient clinics who were aged between 14 and 18 years. German patients (n=26) with CF attending outpatient clinics aged between 13 and 17 years. | Cross- sectional | Pearson’s correlation coefficient | SF-36 Mental health subscore | BMI | ES NR NS | NR
Abbott, 2001^40^ N=84 | English patients (n=58) with CF attending two outpatient clinics who were aged between 14 and 18 years. German patients (n=26) with CF attending outpatient clinics aged between 13 and 17 years. | Cross- sectional | Pearson’s correlation coefficient | SF-36 Mental role limitation subscore | BMI | ES NR NS | NR
Abbott, 2001^40^ N=84 | English patients (n=58) with CF attending two outpatient clinics who were aged between 14 and 18 years. German patients (n=26) with CF attending outpatient clinics aged between 13 and 17 years. | Cross- sectional | Pearson’s correlation coefficient | SF-36 Energy and vitality subscore | BMI | ES NR NR | NR
Abbott, 2001^40^ N=84 | English patients (n=58) with CF attending two outpatient clinics who were aged between 14 and 18 years. German patients (n=26) with CF attending outpatient clinics aged between 13 and 17 years. | Cross- sectional | Pearson’s correlation coefficient | SF-36 General health perceptions subscore | BMI | ES NR NS | NR
Abbott, 2001^40^ N=84 | English patients (n=58) with CF attending two outpatient clinics who were aged between 14 and 18 years. German patients (n=26) with CF attending outpatient clinics aged between 13 and 17 years. | Cross- sectional | Pearson’s correlation coefficient | SF-36 Changes in health subscore | BMI | ES NR NS | NR
Gee, 2003 and 2005^42,43^ N=223 | Patients with CF attending regional adult CF centers. | Cross- sectional | Pearson’s correlation coefficient Multiple regression analysis | CFQoL Physical functioning subscore | BMI | Males ES NR NS Females ES NR NS | ES NR NS
Gee, 2003 and 2005^42,43^ N=223 | Patients with CF attending regional adult CF centers. | Cross- sectional | Pearson’s correlation coefficient Multiple regression analysis | CFQoL Social functioning subscore | BMI | Males ES NR NS Females ES NR NS | ES NR NS
Gee, 2003 and 2005^42,43^ N=223 | Patients with CF attending regional adult CF centers. | Cross- sectional | Pearson’s correlation coefficient Multiple regression analysis | CFQoL Treatment issues subscore | BMI | Males ES NR NS Females ES NR NS | ES NR NS
Gee, 2003 and 2005^42,43^ N=223 | Patients with CF attending regional adult CF centers. | Cross- sectional | Pearson’s correlation coefficient Multiple regression analysis | CFQoL Chest symptoms subscore | BMI | Males r=0.21 p=0.02 Females ES NR NS | ES NR NS
Gee, 2003 and 2005^42,43^ N=223 | Patients with CF attending regional adult CF centers. | Cross- sectional | Pearson’s correlation coefficient Multiple regression analysis | CFQoL Emotional functioning subscore | BMI | Males ES NR NS Females ES NR NS | ES NR NS
Gee, 2003 and 2005^42,43^ N=223 | Patients with CF attending regional adult CF centers. | Cross- sectional | Pearson’s correlation coefficient Multiple regression analysis | CFQoL Concerns for the future subscore | BMI | Males ES NR NS Females r=0.20 p=0.02 | ES NR NS
Gee, 2003 and 2005^42,43^ N=223 | Patients with CF attending regional adult CF centers. | Cross- sectional | Pearson’s correlation coefficient Multiple regression analysis | CFQoL Interpersonal relationships subscore | BMI | Males ES NR NS Females ES NR NS | ES NR NS
Gee, 2003 and 2005^42,43^ N=223 | Patients with CF attending regional adult CF centers. | Cross- sectional | Pearson’s correlation coefficient Multiple regression analysis | CFQoL Body image subscore | BMI | Males r=0.34 p=0.001 Females r=0.55 p=0.001 | β=3.4 (95%CI 2.1, 4.6)
Gee, 2003 and 2005^42,43^ N=223 | Patients with CF attending regional adult CF centers. | Cross- sectional | Pearson’s correlation coefficient Multiple regression analysis | CFQoL Career concerns subscore | BMI | Males ES NR NS Females ES NR NS | ES NR NS
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ Physical function subscore | Height-for age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ Physical function subscore | Weight- for-age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ Role/social limitations –physical subscore | Height-for age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ Role/social limitations –physical subscore | Weight- for-age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ General health perceptions subscore | Height-for age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ General health perceptions subscore | Weight- for-age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ Bodily pain/discomfort subscore | Height-for age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ Bodily pain/discomfort subscore | Weight- for-age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ Role/social limitations –emotional subscore | Height-for age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ Role/social limitations –emotional subscore | Weight- for-age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ Role/social limitations –behavioral subscore | Height-for age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ Role/social limitations –behavioral subscore | Weight- for-age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ Self- esteem subscore | Height-for age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ Self- esteem subscore | Weight- for-age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ Mental health subscore | Height-for age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ Mental health subscore | Weight- for-age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ General behavior subscore | Height-for age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ General behavior subscore | Weight- for-age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ Family activities subscore | Height-for age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ Family activities subscore | Weight- for-age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ Family cohesion subscore | Height-for age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ Family cohesion subscore | Weight- for-age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ Change in health subscore | Height-for age | ES NR NS | NR
Koscik, 2005^44^ N=36 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project, at least age 6.5 years. | Cross- sectional | Spearman’s rank correlation coefficient | CHQ Change in health subscore | Weight- for-age | ES NR NS | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Physical domain | BMI | r=0.11 NS | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Role domain | BMI | r=0.1 NS | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Vitality domain | BMI | r=0.07 NS | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Emotion domain | BMI | r=0.09 NS | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Social domain | BMI | r=0.02 NS | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Body image domain | BMI | r=0.38 p<0.01 | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Eating domain | BMI | r=0.16 p<0.05 | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Treatment burden domain | BMI | r=0.16 p<0.05 | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Health perceptions domain | BMI | r=−0.02 NS | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Respiratory domain | BMI | r=0.11 NS | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Digestive domain | BMI | r=−0.00 NS | NR
Quittner, 2005^45^ N=212 | Adolescents and adults with CF at 18 centers across the United States. | Cross- sectional | NR | CFQ Weight domain | BMI | r=0.47 p<0.01 | NR
Koscik, 2006^50^ N=45 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project between the age of 8 and 18. | Cross- sectional | Generalized linear model | CFQ Physical dimension | Adequate weight gain within 2 years of diagnosis | Model p=0.04 | NR
Koscik, 2006^50^ N=45 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project between the age of 8 and 18. | Cross- sectional | Generalized linear model | CFQ Physical dimension | BMI Z- score >−1 | Model p=0.52 | NR
Koscik, 2006^50^ N=45 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project between the age of 8 and 18. | Cross- sectional | Generalized linear model | CFQ Emotional dimension | Adequate weight gain within 2 years of diagnosis | ES NR NS | NR
Koscik, 2006^50^ N=45 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project between the age of 8 and 18. | Cross- sectional | Generalized linear model | CFQ Emotional dimension | BMI Z- score >−1 | ES NR NS | NR
Koscik, 2006^50^ N=45 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project between the age of 8 and 18. | Cross- sectional | Generalized linear model | CFQ Social dimension | Adequate weight gain within 2 years of diagnosis | ES NR NS | NR
Koscik, 2006^50^ N=45 | Patients with CF from the Wisconsin Newborn Screening (NBS) Project between the age of 8 and 18. | Cross- sectional | Generalized linear model | CFQ Social dimension | BMI Z- score >−1 | ES NR NS | NR
Goldbeck, 2007^46^ N=108 | Adolescent and adult patients with CF, at least age 15 years. | 18 months | Multiple regression analysis | Questions on Life Satisfaction | BMI | NR | ES NR NS
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross-sectional | Pearson correlation | CFQ Physical domain | BMI | NR | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross-sectional | Pearson correlation | CFQ Respiratory domain | BMI | NR | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross-sectional | Pearson correlation | CFQ Vitality domain | BMI | NR | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross-sectional | Pearson correlation | CFQ Social domain | BMI | NR | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross-sectional | Pearson correlation | CFQ Health perceptions domain | BMI | NR | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross-sectional | Pearson correlation | CFQ Treatment domain | BMI | NR | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross-sectional | Pearson correlation | CFQ Role domain | BMI | NR | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross-sectional | Pearson correlation | CFQ Emotion domain | BMI | NR | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross-sectional | Pearson correlation | CFQ Body image domain | BMI | r=0.28 p<0.05 | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross-sectional | Pearson correlation | CFQ Eating domain | BMI | r=0.44 p<0.01 | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross-sectional | Pearson correlation | CFQ Digestion domain | BMI | NR | NR
Havermans, 2008 and 2009^48,49^ N=57 | Adults with CF consecutively attending the Adult CF Center at the University Hospital in Leuven, Belgium clinic between Sept 2006 and Sept 2007. | Cross-sectional | Pearson correlation | CFQ Weight domain | BMI | r=0.43 p<0.01 | NR

Legend: BMI=body mass index; CF=cystic fibrosis; CFQ=Cystic Fibrosis Questionnaire; CFQoL=Cystic Fibrosis Quality of Life questionnaire; CHQ=Child Health Questionnaire; CI=confidence interval; ES=effect size; EQ-5D=EuroQol 5D; IBW=ideal body weight; MCS=mental composite score; NHP=Nottingham Health Profile; NR=not reported; NS=not significant; PCS=physical composite score; QWB=Quality of Well-Being Scale; SF-36=Medical Outcomes Short-Form 36; SIP=Sickness Impact Profile; SS=statistically significant; VAS=visual analog scale

Appendix Table F6 Trials reporting the relationship between exercise tolerance and health-related quality of life

Study, Year | Population/Setting | Duration of Follow-up | Type of Analysis | Outcome | Predictor | Univariate Relationship | Multivariate Relationship
Orenstein, 1989^34^ N=44 | Patients with CF, aged 7 to 36 years, seen at the Pittsburgh Cystic Fibrosis Center | Cross-sectional | Pearson product moment correlation analysis | QWB | Vo_2-peak_ | r=0.5778 p<0.01 | NR
de Jong, 1997^37^ N=15 | Clinically stable patients with CF, aged 16 to 40 years. | Cross-sectional | Spearman’s rank correlation coefficient | SIP Overall Score | W_peak_ | r=−0.57 p<0.05 | NR
de Jong, 1997^37^ N=15 | Clinically stable patients with CF, aged 16 to 40 years. | Cross-sectional | Spearman’s rank correlation coefficient | SIP Physical Subscore | W_peak_ | r=−0.65 p<0.01 | NR
de Jong, 1997^37^ N=15 | Clinically stable patients with CF, aged 16 to 40 years. | Cross-sectional | Spearman’s rank correlation coefficient | SIP Psychosocial Subscore | W_peak_ | r=−0.09 NS | NR

Legend: CF=cystic fibrosis; NR=not reported; NS=not significant; QWB=Quality of Well-Being Scale; SIP=Sickness Impact Profile; Vo_2-peak_=peak oxygen uptake; W_peak_=peak work rate

Appendix Table F7 Trials reporting the relationship between pulmonary function and bone fracture

Study, Year | Population/Setting | Duration of Follow-up | Type of Analysis | Predictor | Univariate Relationship | Multivariate Relationship
Aris, 1998^51^ N=70 | Adults (age >18 years) with advanced CF referred for lung transplantation at the University of North Carolina between Jan 1994 and Dec 1996 that were assessed retrospectively for bone fracture. | NR | Student’s t test | FEV_1_ | ES NR NS | NR
Aris, 1998^51^ N=70 | Adults (age >18 years) with advanced CF referred for lung transplantation at the University of North Carolina between Jan 1994 and Dec 1996 that were assessed retrospectively for bone fracture. | NR | Student’s t test | FVC | ES NR NS | NR

Legend: ES=effect size; BMI=forced expiratory volume in 1 second; FVC=forced vital capacity; FEV_1_=forced expiratory volume in 1 second; NR=not reported; NS=not significant

Appendix Table F8 Trials reporting the relationship between anthropometrics and bone fracture

Study, Year | Population/Setting | Duration of Follow-up | Type of Analysis | Predictor | Univariate Relationship | Multivariate Relationship
Aris, 1998^51^ N=70 | Adults (age >18 years) with advanced CF referred for lung transplantation at the University of North Carolina between Jan 1994 and Dec 1996 that were assessed retrospectively for bone fracture. | NR | Student’s t test | BMI | ES NR NS | NR

Legend: BMI=body mass index; ES=effect size; NR=not reported; NS=not significant

Appendix Table F9 Strength of evidence for outcomes evaluated in Key Question 1

Quality assessment | | | | | | | Summary of findings | | | | | | Importance
Quality assessment | | | | | | | No of patients | | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | rhGH | | Control | Relative (95% CI) | Absolute | Quality | Importance
Pulmonary Function—Change from Baseline in Absolute FVC (L)
3 | Controlled trials | Serious^1^ | No serious inconsistency | No serious indirectness | No serious imprecision | None | 52 | | 48 | - | MD 0.67 higher (0.24 to 1.09 higher) | MODERATE | IMPORTANT
1 | Single-group observational studies | No serious limitations | Serious^2^ | No serious indirectness | Serious^4^ | None | 9 | | 0 | - | Not pooled | INSUFFICIENT | IMPORTANT
Pulmonary Function—Change from Baseline in Percent Predicted FVC
5 | Controlled trials | Serious^1^ | Serious^3^ | No serious indirectness | No serious imprecision | None | 84 | | 60 | - | MD 9.34 higher (3.41 to 15.27 higher) | LOW | IMPORTANT
2 | Single-group observational studies | No serious limitations | Serious^5^ | No serious indirectness | Serious^4^ | None | 18 | | 0 | - | Not pooled | INSUFFICIENT | IMPORTANT
Pulmonary Function—Change from Baseline in Absolute FEV_1_ (L)
4 | Controlled trials | Serious^1^ | No serious inconsistency | No serious indirectness | No serious imprecision | None | 58 | | 52 | - | MD 0.23 higher (0.01 to 0.46 higher) | MODERATE | IMPORTANT
1 | Single-group observational studies | No serious limitations | Serious^2^ | No serious indirectness | Serious^4^ | None | 9 | | 0 | - | Not pooled | INSUFFICIENT | IMPORTANT
Pulmonary Function—Change from Baseline in Percent Predicted FEV_1_
4 | Controlled trials | Serious^1^ | No serious inconsistency | No serious indirectness | No serious imprecision | None | 71 | | 48 | - | MD 2.43 higher (3.99 lower to 8.85 higher) | MODERATE | IMPORTANT
2 | Single-group observational studies | No serious limitations | Serious^5^ | No serious indirectness | Serious^4^ | None | 14 | | 0 | - | Not pooled | INSUFFICIENT | IMPORTANT
Pulmonary Function—Change from Baseline in FEV_1_ Z-score
1 | Controlled trials | Serious^1^ | Serious^2^ | No serious indirectness | Serious^4^ | None | 42 | 21 | - | MD 0.005 lower (0.22 lower to 0.21 higher) | | INSUFFICIENT | IMPORTANT
Anthropometrics—Change from Baseline in Height (cm)
3 | Controlled trials | Serious^1^ | Serious^3^ | No serious indirectness | No serious imprecision | None | 29 | 25 | - | MD 3.13 higher (0.88 to 5.38 higher) | | LOW | IMPORTANT
1 | Single-group observational studies | No serious limitations | Serious^2^ | No serious indirectness | Serious^4^ | None | 24 | 0 | - | Not pooled | | INSUFFICIENT | IMPORTANT
Anthropometrics—Change from Baseline in Height Velocity (cm/year)
3 | Controlled trials | Serious^1^ | No serious inconsistency | No serious indirectness | No serious imprecision | None | 82 | 57 | - | MD 3.27 higher (2.33 to 4.21 higher) | | MODERATE | IMPORTANT
4 | Single-group observational studies | No serious limitations | Serious^5^ | No serious indirectness | Serious^4^ | None | 43 | 0 | - | Not pooled | | INSUFFICIENT | IMPORTANT
Anthropometrics—Change from Baseline in Height Z-Score
3 | Controlled trials | Serious^1^ | No serious inconsistency | No serious indirectness | No serious imprecision | None | 48 | 45 | - | MD 0.51 higher (0.35 to 0.66 higher) | | MODERATE | IMPORTANT
3 | Single-group observational studies | No serious limitations | No serious inconsistency | No serious indirectness | Serious^4^ | None | 23 | 0 | - | Not pooled | | LOW | IMPORTANT
Anthropometrics—Change from Baseline in Height Percentile
1 | Controlled trials | Serious^1^ | Serious^2^ | No serious indirectness | Serious^4^ | None | 10 | 9 | - | Not pooled | | INSUFFICIENT | IMPORTANT
Anthropometrics—Change from Baseline in Weight (kg)
5 | Controlled trials | Serious^1^ | No serious inconsistency | No serious indirectness | No serious imprecision | None | 100 | 73 | - | MD 1.48 higher (0.62 to 2.33 higher) | | MODERATE | IMPORTANT
1 | Single-group observational studies | No serious limitations | Serious^2^ | No serious indirectness | Serious^4^ | None | 9 | 0 | - | Not pooled | | INSUFFICIENT | IMPORTANT
Anthropometrics—Change from Baseline in Weight Velocity (kg/year)
2 | Controlled trials | Serious^1^ | No serious inconsistency | No serious indirectness | No serious imprecision | None | 40 | 36 | - | MD 2.15 higher (1.52 to 2.78 higher) | | MODERATE | IMPORTANT
3 | Single-group observational studies | No serious limitations | No serious inconsistency | No serious indirectness | Serious^4^ | None | 25 | 0 | - | Not pooled | | LOW | IMPORTANT
Anthropometrics—Change from Baseline in Weight Z-score
4 | Controlled trials | Serious^1^ | Serious^3^ | No serious indirectness | No serious imprecision | None | 45 | 43 | - | MD 0.49 higher (0.02 lower to 1 higher) | | LOW | IMPORTANT
1 | Single-group observational studies | No serious limitations | Serious^2^ | No serious indirectness | Serious^4^ | None | 5 | 0 | - | Not pooled | | INSUFFICIENT | IMPORTANT
Anthropometrics—Change from Baseline in Weight Percentile
1 | Controlled trials | Serious^1^ | Serious^2^ | No serious indirectness | Serious^4^ | None | 10 | 9 | - | Not pooled | | INSUFFICIENT | IMPORTANT
Anthropometrics—Change from Baseline in Body Mass Index (kg/m^2^)
2 | Controlled trials | Serious^1^ | No serious inconsistency | No serious indirectness | No serious imprecision | None | 22 | 21 | - | MD 2.08 higher (1.2 to 2.96 higher) | | MODERATE | IMPORTANT
1 | Single-group observational studies | No serious limitations | Serious^2^ | No serious indirectness | Serious^4^ | None | 5 | 0 | - | Not pooled | | INSUFFICIENT | IMPORTANT
Anthropometrics—Change from Baseline in BMI Z-score
1 | Controlled trials | Serious^1^ | Serious^2^ | No serious indirectness | Serious^4^ | None | 42 | 21 | - | MD 0.05 lower (0.3 lower to 0.2 higher) | | INSUFFICIENT | IMPORTANT
Anthropometrics—Change from Baseline in Percent Ideal Body Weight
2 | Controlled trials | Serious^1^ | No serious inconsistency | No serious indirectness | Serious^4^ | None | 23 | 21 | - | MD 12.57 higher (7.01 to 18.12 higher) | | LOW | IMPORTANT
Anthropometrics—Change from Baseline in Lean Body Mass (kg)
8 | Controlled trials | Serious^1^ | No serious inconsistency | No serious indirectness | No serious imprecision | None | 149 | 121 | - | MD 1.92 higher (1.47 to 2.37 higher) | | MODERATE | IMPORTANT
Protein Turnover
2 | Controlled trials | Serious^1^ | Serious^5^ | No serious indirectness | Serious^4^ | None | 28 | 18 | - | Not pooled | | INSUFFICIENT | IMPORTANT
1 | Single-group observational studies | No serious limitations | Serious 2 | No serious indirectness | Serious 4 | None | 9 | 0 | - | Not pooled | | INSUFFICIENT | IMPORTANT
Exercise Tolerance
3 | Controlled trials | Serious^1^ | Serious^5^ | No serious indirectness | Serious 4 | None | 58 | 34 | - | Not pooled | | INSUFFICIENT | IMPORTANT
1 | Single-group observational studies | No serious limitations | Serious^2^ | No serious indirectness | Serious 4 | None | 5 | 0 | - | Not pooled | | INSUFFICIENT | IMPORTANT
Bone Mineralization — Bone Age (years)
2 | Controlled trials | Serious^1^ | Serious^5^ | No serious indirectness | Serious^4^ | None | 23 | 21 | - | Not pooled | | INSUFFICIENT | IMPORTANT
3 | Single-group observational studies | No serious limitations | No serious inconsistency | No serious indirectness | Serious^4^ | None | 21 | 0 | - | Not pooled | | LOW | IMPORTANT
Bone Mineralization — Change from Baseline in Bone Mineral Content (g)
4 | Controlled trials | Serious^1^ | Serious^3^ | No serious indirectness | No serious imprecision | None | 68 | 64 | - | MD 192 higher(110 to 273 higher) | | LOW | IMPORTANT
Bone Mineralization — Bone Mineral Content Z-score
1 | Controlled trials | Serious^1^ | Serious^2,5^ | No serious indirectness | Serious^4^ | None | 32 | 29 | - | Not pooled | | INSUFFICIENT | IMPORTANT
Sexual Maturation
7 | Controlled trials | Serious^1^ | Serious^5^ | No serious indirectness | No serious imprecision | None | 104 | 88 | Not pooled | Not pooled | | LOW | IMPORTANT

Legend: BMI=body mass index; CI=confidence interval; FEV_1_=forced expiratory volume in one second; FVC=forced vital capacity; MD=mean difference; rhGH=recombinant human growth hormone

1 Lack of or inadequate information about blinding

2 Single study

3 Statistical heterogeneity detected

4 Inadequately powered

5 Inconsistent study designs or outcomes reporting

Appendix Table F10 Strength of evidence for outcomes evaluated in Key Question 2

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | rhGH | Control | Relative (95% CI) | Absolute | Quality | Importance
Antibiotic Usage
3 | Controlled trials | Serious^1^ | Serious^2^ | No serious indirectness | Serious^3^ | None | 51 | 47 | - | Not pooled | INSUFFICIENT | IMPORTANT
Pulmonary Exacerbations
1 | Controlled trials | Serious^1^ | Serious^4^ | No serious indirectness | Serious^3^ | None | 13/42 (31%) | 4/21 (19%) | RR 1.63 (0.60 to 4.38) | 12% Risk Increase | INSUFFICIENT | IMPORTANT
Change from Baseline in Rate of Hospitalizations (events per year)
4 | Controlled trials | Serious^1^ | No serious inconsistency | No serious indirectness | No serious imprecision | None | 62 | 57 | - | MD 1.62 lower (1.98 to 1.26 lower) | MODERATE | IMPORTANT
Health-Related Quality of Life
2 | Controlled trials | Serious^1^ | Serious^2^ | No serious indirectness | Serious^3^ | None | 74 | 50 | - | Not pooled | INSUFFICIENT | IMPORTANT

Legend: CI=confidence interval; MD=mean difference; rhGH=recombinant human growth hormone

1 Lack of or inadequate information about blinding

2 Inconsistent study designs or outcomes reporting

3 Inadequately powered

4 Single study

Appendix Table F11 Strength of evidence for outcomes evaluated in Key Question 4

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | rhGH | Control | Relative (95% CI) | Absolute | Quality | Importance
Change from Baseline in A1c (%)
2 | Controlled trials | Serious^1^ | No serious inconsistency | No serious indirectness | Serious^2^ | None | 23 | 21 | - | MD 0.10 lower (0.4 lower to 0.2 higher) | LOW | IMPORTANT
2 | Single-group observational studies | No serious limitations | No serious inconsistency | No serious indirectness | Serious^2^ | None | 18 | 0 | - | Not pooled | LOW | IMPORTANT
Change from Baseline in Random BG (mg/dl)
3 | Controlled trials | Serious^1^ | Serious^3^ | No serious indirectness | Serious^2^ | None | 54 | 50 | - | Not pooled | INSUFFICIENT | IMPORTANT
Change from Baseline in FBG (mg/dl)
2 | Controlled trials | Serious^1^ | No serious inconsistency | No serious indirectness | No serious imprecision | None | 52 | 30 | - | MD 5.68 higher (0.43 to 10.93 higher) | MODERATE | IMPORTANT
1 | Single-group observational studies | No serious limitations | Serious^4^ | No serious indirectness | Serious^2^ | None | 9 | 0 | - | Not pooled | INSUFFICIENT | IMPORTANT
Change from Baseline in Stimulated BG (mg/dl)
1 | Controlled trials | Serious^1^ | Serious^4^ | No serious indirectness | Serious^2^ | None | 42 | 21 | - | MD 4.93 higher (15.13 lower to 24.98 higher) | INSUFFICIENT | IMPORTANT
Change from Baseline in Postprandial BG (mg/dl)
1 | Controlled trials | Serious^1^ | Serious^4^ | No serious indirectness | Serious^2^ | None | 10 | 9 | - | MD 10 higher (17.91 lower to 37.91 higher) | INSUFFICIENT | IMPORTANT
Change from Baseline in Other BG Parameters Not Specified (mg/dl)
1 | Controlled trials | Serious^1^ | Serious^4^ | No serious indirectness | Serious^2^ | None | 18 | 9 | - | Not pooled | INSUFFICIENT | IMPORTANT
1 | Single-group observational studies | Serious^1^ | Serious^4^ | No serious indirectness | Serious^2^ | None | 5 | 0 | - | Not pooled | INSUFFICIENT | IMPORTANT
Development of Glucose Intolerance
7 | Controlled trials | Serious^1^ | No serious inconsistency | No serious indirectness | Serious^2^ | None | 0/61 (0%) | 0/54 (0%) | Not pooled | Not pooled | LOW | IMPORTANT
3 | Observational trials | Serious^1^ | No serious inconsistency | No serious indirectness | Serious^2^ | None | 2/42 (4.8%) | 0/0 | Not pooled | Not pooled | INSUFFICIENT | IMPORTANT
Development of Diabetes
7 | Controlled trials | Serious^1^ | No serious inconsistency | No serious indirectness | Serious^2^ | None | 0/61 (0%) | 0/54 (0%) | Not pooled | Not pooled | LOW | IMPORTANT
1 | Single-group observational studies | Serious^1^ | Serious^4^ | No serious indirectness | Serious^2^ | None | 1/1 (100%) | 0/0 | Not pooled | Not pooled | INSUFFICIENT | IMPORTANT

Legend: A1c=glycosylated hemoglobin; BG=blood glucose; CI=confidence interval; MD=mean difference; rhGH=recombinant human growth hormone

1 Lack of or inadequate information about blinding

2 Inadequately powered

3 Inconsistent study designs or outcomes reporting

4 Single study

Appendix Table F12 Strength of evidence for outcomes evaluated in Key Question 5

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | rhGH | Control | Relative (95% CI) | Absolute | Quality | Importance
Biomarkers – IGF-I (ng/ml)
4 | Controlled trials | Serious^1^ | Serious^2^ | No serious indirectness | Serious^3^ | None | 66 | 55 | - | Not pooled | INSUFFICIENT | IMPORTANT
2 | Single-group observational studies | No serious limitations | No serious inconsistency | No serious indirectness | Serious^3^ | None | 14 | 0 | - | Not pooled | INSUFFICIENT | IMPORTANT
Biomarkers – IGFBP-3 (ng/ml)
1 | Controlled trials | Serious^1^ | Serious^4^ | No serious indirectness | Serious^3^ | None | 18 | 9 | - | Not pooled | INSUFFICIENT | IMPORTANT
1 | Single-group observational studies | No serious limitations | Serious^4^ | No serious indirectness | Serious^3^ | None | 5 | 0 | - | Not pooled | INSUFFICIENT | IMPORTANT
Development of Cancer in CF Populations
1 | Single-group observational studies | Serious^1^ | Serious^4^ | No serious indirectness | Serious^3^ | None | 1 | 0 | Not pooled | Not pooled | INSUFFICIENT | IMPORTANT
Development of Cancer in Non-CF Populations
3 | Single-group observational studies | No serious limitations | No serious inconsistency | Serious^5^ | No serious imprecision | None | 33,172 | 0 | Not pooled | Not pooled | LOW | IMPORTANT

Legend: CF=cystic fibrosis; CI=confidence interval; IGF-I=insulin-like growth factor-1; IGFBP-3=insulin-like growth factor binding protein-3; MD=mean difference; rhGH=recombinant human growth hormone

1 Lack of or inadequate information about blinding

2 Inconsistent study designs or outcomes reporting

3 Inadequately powered

4 Single study

5 Studies not in patients with CF

## References for Appendix F

Please note that these references are independent of the main report and may have different reference numbers.

1 Huang NN, Schidlow DV, Szatrowski TH, et al. Clinical features, survival rate, and prognostic factors in young adults with cystic fibrosis. Am J Med. 1987;82(5):871-879. [pmid: 3578357].
2 Corey M, McLaughlin FJ, Williams M, et al. A comparison of survival, growth, and pulmonary function in patients with cystic fibrosis in Boston and Toronto. J Clin Epidemiol. 1988;41(6):583-591. [pmid: 3260274].
3 Kerem E, Reisman J, Corey M, et al. Prediction of mortality in patients with cystic fibrosis. N Engl J Med. 1992;326(18):1187-91. [pmid: 1285737].
4 Nixon PA, Orenstein DM, Kelsey SF, et al. The prognostic value of exercise testing in patients with cystic fibrosis. N Engl J Med. 1992;327(25):1785-1788. [pmid: 1435933].
5 Sharples L, Hathaway T, Dennis C, et al. Prognosis of patients with cystic fibrosis awaiting heart and lung transplantation. J Heart Lung Transplant. 1993;12(4):669-674. [pmid: 8369328].
6 Ciriaco P, Egan TM, Cairns EL, et al. Analysis of cystic fibrosis referrals for lung transplantation. Chest. 1995;107(5):1323-1327. [pmid: 7750326].
7 Corey M, Farewell V. Determinants of mortality from cystic fibrosis in Canada, 1970–1989. Am J Epidemiol. 1996;143(10):1007-1017. [pmid: 8629607].
8 Corey M, Edwards L, Levison H, et al. Longitudinal analysis of pulmonary function decline in patients with cystic fibrosis. J Pediatr. 1997;131(6):809-814. [pmid: 9427882].
9 Hayllar KM, Williams SG, Wise AE, et al. A prognostic model for the prediction of survival in cystic fibrosis. Thorax. 1997;52(4):313-317. [pmid: 9196511].
10 Moorcroft AJ, Dodd ME, Webb AK. Exercise testing and prognosis in adult cystic fibrosis. Thorax. 1997;52(3):291-293. [pmid: 9093351].
11 Rosenfeld M, Davis R, FitzSimmons S, et al. Gender gap in cystic fibrosis mortality. Am J Epidemiol. 1997;145(9):794-803. [pmid: 9143209].
12 Bell SC, Bowerman AR, Davies CA, et al. Nutrition in adults with cystic fibrosis. Clin Nutr. 1998;17(5):211-215. [pmid: 10205341].
13 Milla CE, Warwick WJ. Risk of death in cystic fibrosis patients with severely compromised lung function. Chest. 1998;113(5):1230-1234. [pmid: 9596299].
14 Venuta F, Rendina EA, De Giacomo T, et al. Timing and priorities for cystic fibrosis patients candidates to lung transplantation. Eur J Pediatr Surg. 1998;8(5):274-277. [pmid: 9825236].
15 Robinson W, Waltz DA. FEV(1) as a guide to lung transplant referral in young patients with cystic fibrosis. Pediatr Pulmonol. 2000;30(3):198-202. [pmid: 10973037].
16 Vizza CD, Yusen RD, Lynch JP, et al. Outcome of patients with cystic fibrosis awaiting lung transplantation. Am J Respir Crit Care Med. 2000;162(3 Pt 1):819-825. [pmid: 10988089].
17 Liou TG, Adler FR, Fitzsimmons SC, et al. Predictive 5-year survivorship model of cystic fibrosis. Am J Epidemiol. 2001;153(4):345-352. [pmid: 11207152].
18 Sharma R, Florea VG, Bolger AP, et al. Wasting as an independent predictor of mortality in patients with cystic fibrosis. Thorax. 2001;56(10):746-750. [pmid: 11562511].
19 Mayer-Hamblett N, Rosenfeld M, Emerson J, et al. Developing cystic fibrosis lung transplant referral criteria using predictors of 2-year mortality. Am J Respir Crit Care Med. 2002;166(12 Pt 1):1550-1555. [pmid: 12406843].
20 Schaedel C, de Monestrol I, Hjelte L, et al. Predictors of deterioration of lung function in cystic fibrosis. Pediatr Pulmonol. 2002;33(6):483-491. [pmid: 12001283].
21 Stanchina ML, Tantisira KG, Aquino SL, et al. Association of lung perfusion disparity and mortality in patients with cystic fibrosis awaiting lung transplantation. J Heart Lung Transplant. 2002;21(2):217-225. [pmid: 11834350].
22 Vedam H, Moriarty C, Torzillo PJ, et al. Improved outcomes of patients with cystic fibrosis admitted to the intensive care unit. J Cyst Fibros. 2004;3(1):8-14. [pmid: 15463881].
23 Ellaffi M, Vinsonneau C, Coste J, et al. One-year outcome after severe pulmonary exacerbation in adults with cystic fibrosis. Am J Respir Crit Care Med. 2005;171(2):158-164. [pmid: 15502116].
24 Pianosi P, Leblanc J, Almudevar A. Peak oxygen uptake and mortality in children with cystic fibrosis. Thorax. 2005;60(1):50-54. [pmid: 15618583].
25 Belkin RA, Henig NR, Singer LG, et al. Risk factors for death of patients with cystic fibrosis awaiting lung transplantation. Am J Respir Crit Care Med. 2006;173(6):659-666. [pmid: 16387803].
26 Texereau J, Jamal D, Choukroun G, et al. Determinants of mortality for adults with cystic fibrosis admitted in Intensive Care Unit: a multicenter study. Respir Res. 2006;7:14. [pmid: 16438722].
27 Courtney JM, Bradley J, Mccaughan J, et al. Predictors of mortality in adults with cystic fibrosis. Pediatr Pulmonol. 2007;42(6):525-532. [pmid: 17469153].
28 Rosenthal M. Annual assessment spirometry, plethysmography, and gas transfer in cystic fibrosis: do they predict death or transplantation. Pediatr Pulmonol. 2008;43(10):945-952. [pmid: 18781653].
29 Kraemer R, Rudeberg A, Hadorn B, et al. Relative underweight in cystic fibrosis and its prognostic value. Acta Paediatr Scand. 1978;67(1):33-37. [pmid: 626067].
30 Beker LT, Russek-Cohen E, Fink RJ. Stature as a prognostic factor in cystic fibrosis survival. J Am Diet Assoc. 2001;101(4):438-442. [pmid: 11320950].
31 Emerson J, Rosenfeld M, McNamara S, et al. Pseudomonas aeruginosa and other predictors of mortality and morbidity in young children with cystic fibrosis. Pediatr Pulmonol. 2002;34(2):91-100. [pmid: 12112774].
32 Banjar H. Morbidity and mortality data of cystic fibrosis patients. Saudi Med J. 2003;24(7):730-735. [pmid: 12883603].
33 Kadikar A, Maurer J, Kesten S. The six-minute walk test: a guide to assessment for lung transplantation. J Heart Lung Transplant. 1997;16(3):313-9. [pmid: 9087875].
34 Orenstein DM, Nixon PA, Ross EA, et al. The quality of well-being in cystic fibrosis. Chest. 1989;95:344-347. [pmid: 2914486].
35 Czyzewski DI, Mariotto MJ, Bartholomew LK, et al. Measurement of quality of well being in a child and adolescent cystic fibrosis population. Med Care. 1994;32(9):965-972. [pmid: 8090048].
36 Congleton J, Hodson ME, Duncan-Skingle F. Quality of life in adults with cystic fibrosis. Thorax. 1996;51(9):936-940. [pmid: 8984707].
37 de Jong W, Kaptein AA, van der Schans CP, et al. Quality of life in patients with cystic fibrosis. Pediatr Pulmonol. 1997;23(2):95-100. [pmid: 9065946].
38 Staab D, Wenninger K, Gebert N, et al. Quality of life in patients with cystic fibrosis and their parents: what is important besides disease severity?. Thorax. 1998;53(9):727-731. [pmid: 10319053].
39 Johnson JA, Connolly M, Zuberbuhler P, et al. Health-related quality of life for adults with cystic fibrosis: a regression approach to assessing the impact of recombinant human DNase. Pharmacotherapy. 2000;20(10):1167-1174. [pmid: 11034039].
40 Abbott J, Baumann U, Conway S, et al. Cross cultural differences in health related quality of life in adolescents with cystic fibrosis. Disabil Rehabil. 2001;23(18):837-844. [pmid: 11763280].
41 Powers PM, Gerstle R, Lapey A. Adolescents with cystic fibrosis: family reports of adolescent health-related quality of life and forced expiratory volume in one second. Pediatrics. 2001;107(5):E70. [pmid: 11331720].
42 Gee L, Abbott J, Conway SP, Etherington C, Webb AK. Quality of life in cystic fibrosis: the impact of gender, general health perceptions and disease severity. J Cyst Fibros. 2003;2(4):206-213. [pmid: 15463875].
43 Gee L, Abbott J, Hart A, et al. Associations between clinical variables and quality of life in adults with cystic fibrosis. J Cyst Fibros. 2005;4(1):59-66. [pmid: 15752683].
44 Koscik RL, Douglas JA, Zaremba K, et al. Quality of life of children with cystic fibrosis. J Pediatr. 2005;147(3 Suppl):S64-S68. [pmid: 16202786].
45 Quittner AL, Buu A, Messer MA, et al. Development and validation of The Cystic Fibrosis Questionnaire in the United States: a health-related quality-of-life measure for cystic fibrosis. Chest. 2005;128(4):2347-2354. [pmid: 16236893].
46 Goldbeck L, Zerrer S, Schmitz TG. Monitoring quality of life in outpatients with cystic fibrosis: feasibility and longitudinal results. J Cyst Fibros. 2007;6(3):171-178. [pmid: 16877050].
47 Riekert KA, Bartlett SJ, Boyle MP, et al. The association between depression, lung function, and health-related quality of life among adults with cystic fibrosis. Chest. 2007;132(1):231-237. [pmid: 17625085].
48 Havermans T, Colpaert K, Dupont LJ. Quality of life in patients with Cystic Fibrosis: association with anxiety and depression. J Cyst Fibros. 2008;7(6):581-584. [pmid: 18692444].
49 Havermans T, Colpaert K, Vanharen L, et al. Health related quality of life in cystic fibrosis: To work or not to work?. J Cyst Fibros. 2009;8(3):218-223. [pmid: 19328745].
50 Koscik RL, Shoff S, Lai H, et al. Is recovery of birth weight Z-score within 2 years of diagnosis related to quality of life in later childhood [abstract]. Pediatr Pulmonol. 2006;41(Suppl 29):400.
51 Aris RM, Renner JB, Winders AD, et al. Increased rate of fractures and severe kyphosis: sequelae of living into adulthood with cystic fibrosis. Ann Intern Med. 1998;128(3):186-193. [pmid: 9454526].