# Abbreviations

A1c: Glycosylated hemoglobin A1c
AHRQ: Agency for Healthcare Research and Quality
BG: Blood glucose
BIA: Bio-electrical impedance assessment
BMC: Bone mineral content
BMI: Body mass index
cc: Cubic centimeters, also milliters
CDC: Centers for Disease Control and Prevention
CER: Comparative effectiveness review
CF: Cystic fibrosis
CFRD: Cystic fibrosis-related diabetes
CFTR: Cystic fibrosis transmembrane regulator
CI: Confidence interval
DEXA: Dual energy x-ray absorptiometry
EPC: Evidence-based Practice Center
^f^: Value for females
FEV_1_: Forced expiratory volume in one second
FVC: Forced vital capacity
GHD: Growth hormone deficiency
GLN: Glutamate
GRADE: Grading of Recommendations Assessment, Development and Evaluation
hGH: Human growth hormone
HRQoL: Health-related quality-of-life
IGF-I: Insulin-like growth factor-1
IGFBP-3: Insulin-like growth factor binding protein-3
IQR: Interquartile range
ISS: Idiopathic short stature
LBM: Lean body mass
Leu: Leucine
LeuRa: Rate of appearance of leucine
LeuOx: Rate of oxidation of leucine
^m^: Value for males
NOLD: Rate of nonoxidative leucine disappearance
NR: Not reported
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta- Analyses
RCT: Randomized controlled trials
rhGH: Recombinant human growth hormone
RR: Relative risk, also risk ratio
SD: Standard deviation
SDS: Standard deviation score
SMD: Standardized mean difference
TEP: Technical Expert Panel
ULN: Upper limit of normal
Vo_2_: Oxygen uptake
Vo_2_-max: Maximum oxygen uptake
Vo_2_-peak: Peak oxygen uptake
W: Watt
WHO: World Health Organization
WMD: Weighted mean difference