# Excluded Studies from Searches

Excluded Studies from Full-Text Review of Key Questions 1, 2, 4, 6, and 7 Search

Reference | Reason for Exclusion
Bucuvalas JC, Chernausek SD. Growth hormone and cystic fibrosis: Good for more than growth? J Pediatr 2001;139:616–618. | Not a report of a new discovery
Colombo C, Battezzati A. Growth failure in cystic fibrosis: A true need for anabolic agents? J Pediatr 2005;146:303–305. | Not a report of a new discovery

Legend: CF=cystic fibrosis; rhGH=recombinant human growth hormone

Excluded Studies from Full-Text Review of Key Question 3 Search

Reference | Reason for Exclusion
Abbott J, Hart A, Morton AM, et al. Can health-related quality of life predict survival in adults with cystic fibrosis? Am J Respir Crit Care Med 2009;179:54–58. | Not evaluating the link between intermediate outcomes and important health outcomes
Abbott J, Morton AM, Musson H, et al. Nutritional status, perceived body image and eating behaviours in adults with cystic fibrosis. Clin Nutr 2007;26:91–99. | Not evaluating the link between intermediate outcomes and important health outcomes
Abman SH, Accurso FJ, Bowman CM. Persistent morbidity and mortality of protein calorie malnutrition in young infants with CF. J Pediatr Gastroenterol Nutr 1986;5:393–396. | Not evaluating the link between intermediate outcomes and important health outcomes
Aebi C, Bracher R, Liechti-Gallati S, et al. The age at onset of chronic pseudomonas aeruginosa colonization in cystic fibrosis prognostic significance. Eur J Pediatr 1995;154:S69–S73. | Not evaluating the link between intermediate outcomes and important health outcomes
Amadori A, Antonelli A, Balteri I, et al. Recurrent exacerbations affect FEV(1) decline in adult patients with cystic fibrosis. Respir Med 2009;103:407–413. | Not evaluating the link between intermediate outcomes and important health outcomes
Amelina E, Senkevich N, Cherniak A, et al. Home intravenous therapy in adult cystic fibrosis patients. The impact on lung function and quality of life [abstract]. European Respiratory Journal 2000;16:123s. | Not evaluating the link between intermediate outcomes and important health outcomes
Aris RM, Stephens AR, Ontjes DA, et al. Adverse alterations in bone metabolism are associated with lung infection in adults with cystic fibrosis. Am J Respir Crit Care Med 2000;162:1674–1678. | Not evaluating the link between intermediate outcomes and important health outcomes
Arrington-Sanders R, Yi MS, Tsevat J, et al. Gender differences in health-related quality of life of adolescents with cystic fibrosis. Health Qual Life Outcomes 2006;4:5. | Not evaluating the link between intermediate outcomes and important health outcomes
Assael BM, Casazza G, Iansa P, et al. Growth and long-term lung function in cystic fibrosis: A longitudinal study of patients diagnosed by neonatal screening. Pediatr Pulmonol 2009;44:209–215. | Not evaluating the link between intermediate outcomes and important health outcomes
Aurora P, Whitehead B, Wade A, et al. Lung transplantation and life extension in children with cystic fibrosis. Lancet 1999;354:1591–1593. | Evaluating terminal outcomes after an intervention
Berlinski A, Fan LL, Kozinetz CA, et al. Invasive mechanical ventilation for acute respiratory failure in children with cystic fibrosis: Outcome analysis and case-control study. Pediatr Pulmonol 2002;34:297–303. | Not evaluating the link between intermediate outcomes and important health outcomes
Bismuth E, Laborde K, Taupin P, et al. Glucose tolerance and insulin secretion, morbidity, and death in patients with cystic fibrosis. J Pediatr 2008 545.e1;152:540; Ar-545. | Not evaluating the link between intermediate outcomes and important health outcomes
Bizzarri C, Lucidi V, Ciampalini P, et al. Clinical effects of early treatment with insulin glargine in patients with cystic fibrosis and impaired glucose tolerance. J Endocrinol Invest 2006;29:R1–R4. | Not evaluating the link between intermediate outcomes and important health outcomes
Bradley J, McAlister O, Elborn S. Pulmonary function, inflammation, exercise capacity and quality of life in cystic fibrosis. Eur Respir J 2001;17:712–715. | Not evaluating the link between intermediate outcomes and important health outcomes
Britto MT, Kotagal UR, Hornung RW, et al. Impact of recent pulmonary exacerbations on quality of life in patients with cystic fibrosis. Chest 2002;121:64–72. | Not evaluating the link between intermediate outcomes and important health outcomes
Callaghan BD, Hoo AF, Dinwiddie R, et al. Growth and lung function in Asian patients with cystic fibrosis. Arch Dis Child 2005;90:1029–1032. | Not evaluating the link between intermediate outcomes and important health outcomes
Camargos PA, Guimaraes MD, Reis FJ. Prognostic aspects of cystic fibrosis in Brazil. Ann Trop Paediatr 2000;20:287–291. | Not evaluating the link between intermediate outcomes and important health outcomes
Christian B. The impact of chronic illness on quality of life in children with cystic fibrosis [abstract]. Pediatr Pulmonol 2006;41:398. | Not evaluating the link between intermediate outcomes and important health outcomes
Christian B. Functional disability and quality of life of school-age children with cystic fibrosis [abstract]. Pediatr Pulmonol 2004;38:356. | Evaluating terminal outcomes after an intervention
Corey M, Gaskin K, Durie P, et al. Improved prognosis in CF patients with normal fat absorption. J Pediatr Gastroenterol Nutr 1984;3:S99– S105. | Not evaluating the link between intermediate outcomes and important health outcomes
Curtis JR, Burke W, Kassner AW, et al. Absence of health insurance is associated with decreased life expectancy in patients with cystic fibrosis. Am J Respir Crit Care Med 1997;155:1921–1924. | Not evaluating the link between intermediate outcomes and important health outcomes
Dalzell AM, Shepherd RW, Dean B, et al. Nutritional rehabilitation in cystic fibrosis: A 5 year follow-up study. J Pediatr Gastroenterol Nutr 1992;15:141–145. | Not evaluating the link between intermediate outcomes and important health outcomes
Dodd ME, Abbott J, Haworth CS, et al. Validity of a visual numerical general quality of life scale and chest scale in adults with cystic fibrosis [abstract]. Thorax 1997;52:A45. | Not evaluating the link between intermediate outcomes and important health outcomes
Dodge JA, Lewis PA, Stanton M, et al. Cystic fibrosis mortality and survival in the UK: 1947–2003. Eur Respir J 2007;29:522–526. | Not evaluating the link between intermediate outcomes and important health outcomes
Dodge JA, Morison S, Lewis PA, et al. Cystic fibrosis in the United Kingdom, 1968–1988: Incidence, population and survival. Paediatr Perinat Epidemiol 1993;7:157–166. | Not evaluating the link between intermediate outcomes and important health outcomes
Doull IJM, Ryley HC, Weller P, et al. Death from cystic fibrosis in the first five years of life and the effect of newborn screening [abstract]. XIIIth International Cystic Fibrosis Congress; 2000 Jun 4–8; Stockholm, Sweden. | Not evaluating the link between intermediate outcomes and important health outcomes
Dunnink MA, Doeleman WR, Trappenburg JC, et al. Respiratory muscle strength in stable adolescent and adult patients with cystic fibrosis. J Cyst Fibros 2009;8:31–36. | Not evaluating the link between intermediate outcomes and important health outcomes
Escobar MA, Grosfeld JL, Burdick JJ, et al. Surgical considerations in cystic fibrosis: A 32-year evaluation of outcomes. Surgery 2005;138:560–571. | Not evaluating the link between intermediate outcomes and important health outcomes
Filliozat AM, Hennequet A. Psychological development and cystic fibrosis. Ann Pediatr (Paris) 1976;23:47–52. | Not in CF patients
Hodson ME, Simmonds NJ, Warwick WJ, et al. An international/multicentre report on patients with cystic fibrosis (CF) over the age of 40 years. J Cyst Fibros 2008;7:537–542. | Not evaluating the link between intermediate outcomes and important health outcomes
Hogg M, Braithwaite M, Bailey M, et al. Work disability in adults with cystic fibrosis and its relationship to quality of life. J Cyst Fibros 2007;6:223–227. | Not evaluating the link between intermediate outcomes and important health outcomes
Jarad NA, Giles K. Risk factors for increased need for intravenous antibiotics for pulmonary exacerbations in adult patients with cystic fibrosis. Chron respir dis 2008;5:29–33. | Not evaluating the link between intermediate outcomes and important health outcomes
Kalish LA, Waltz DA, Dovey M, et al. Impact of burkholderia dolosa on lung function and survival in cystic fibrosis. Am J Respir Crit Care Med 2006;173:421–425. | Not evaluating the link between intermediate outcomes and important health outcomes
Kulich M, Rosenfeld M, Goss CH, et al. Improved survival among young patients with cystic fibrosis. J Pediatr 2003;142:631–636. | Not evaluating the link between intermediate outcomes and important health outcomes
Liou TG, Adler FR, Cox DR, et al. Lung transplantation and survival in children with cystic fibrosis. N Engl J Med 2007;357:2143–2152. | Evaluating terminal outcomes after an intervention
Liou TG, Adler FR, Huang D. Use of lung transplantation survival models to refine patient selection in cystic fibrosis. Am J Respir Crit Care Med 2005;171:1053–1059. | Not evaluating the link between intermediate outcomes and important health outcomes
Maisonneuve P, FitzSimmons SC, Neglia JP, et al. Cancer risk in nontransplanted and transplanted cystic fibrosis patients: A 10-year study. J Natl Cancer Inst 2003;95:381–387. | Not evaluating the link between intermediate outcomes and important health outcomes
Milla CE, Billings J, Moran A. Diabetes is associated with dramatically decreased survival in female but not male subjects with cystic fibrosis. Diabetes Care 2005;28:2141–2144. | Not evaluating the link between intermediate outcomes and important health outcomes
Miller RJ, Tildesley HD, Wilcox PG, et al. Sex disparities in effects of cystic fibrosis-related diabetes on clinical outcomes: A matched study. Can Respir J 2008;15:291–294. | Not evaluating the link between intermediate outcomes and important health outcomes
Munzenberger PJ, Van Wagnen CA, Abdulhamid I, et al. Quality of life as a treatment outcome in patients with cystic fibrosis. Pharmacotherapy 1999;19:393–398. | Not evaluating the link between intermediate outcomes and important health outcomes
Neglia JP, FitzSimmons SC, Maisonneuve P, et al. The risk of cancer among patients with cystic fibrosis. cystic fibrosis and cancer study group. N Engl J Med 1995;332:494–499. | Not evaluating the link between intermediate outcomes and important health outcomes
Neglia JP, Wielinski CL, Warwick WJ. Cancer risk among patients with cystic fibrosis. J Pediatr 1991;119:764–766. | Not evaluating the link between intermediate outcomes and important health outcomes
Palermo TM, Harrison D, Koh JL. Effect of disease-related pain on the health-related quality of life of children and adolescents with cystic fibrosis. Clin J Pain 2006;22:532–537. | Not evaluating the link between intermediate outcomes and important health outcomes
Quittner AL, Modi AC, Accurso FJ, et al. Treatment satisfaction, health-related quality of life and airway clearance therapies in patients with cystic fibrosis [abstract]. Pediatr Pulmonol 2004;38:314. | Not evaluating the link between intermediate outcomes and important health outcomes
Rosenecker J, Hofler R, Steinkamp G, et al. Diabetes mellitus in patients with cystic fibrosis: The impact of diabetes mellitus on pulmonary function and clinical outcome. Eur J Med Res 200127;6:345–350. | Not evaluating the link between intermediate outcomes and important health outcomes
Rovner AJ, Zemel BS, Leonard MB, et al. Mild to moderate cystic fibrosis is not associated with increased fracture risk in children and adolescents. J Pediatr 2005;147:327–331. | Not evaluating the link between intermediate outcomes and important health outcomes
Saltzman DA, Johnson EM, Feltis BA, et al. Surgical experience in patients with cystic fibrosis: A 25-year perspective. Pediatr Pulmonol 2002;33:106–110. | Not evaluating the link between intermediate outcomes and important health outcomes
Schluchter MD, Konstan MW, Davis PB. Jointly modelling the relationship between survival and pulmonary function in cystic fibrosis patients. Stat Med 2002;21:1271–1287. | Not evaluating the link between intermediate outcomes and important health outcomes
Selvadurai HC, Blimkie CJ, Cooper PJ, et al. Gender differences in habitual activity in children with cystic fibrosis. Arch Dis Child 2004;89:928–933. | Not evaluating the link between intermediate outcomes and important health outcomes
Sheldon CD, Hodson ME, Carpenter LM, et al. A cohort study of cystic fibrosis and malignancy. Br J Cancer 1993;68:1025–1028. | Not evaluating the link between intermediate outcomes and important health outcomes
Slieker MG, van Gestel JP, Heijerman HG, et al. Outcome of assisted ventilation for acute respiratory failure in cystic fibrosis. Intensive Care Med 2006;32:754–758. | Not evaluating the link between intermediate outcomes and important health outcomes
Sood N, Paradowski LJ, Yankaskas JR. Outcomes of intensive care unit care in adults with cystic fibrosis. Am J Respir Crit Care Med 2001;163:335–338. | Not evaluating the link between intermediate outcomes and important health outcomes
Stern M, Picard C, Grenet D. Mucoviscidosis in adults. Presse Med 2002;31:263–270. | Not in CF patients
Street ME, Spaggiari C, Volta C, et al. The IGF system and cytokine interactions and relationships with longitudinal growth in prepubertal patients with cystic fibrosis. Clin Endocrinol (Oxf) 2009;70:593–598. | Not evaluating the link between intermediate outcomes and important health outcomes
Suri R, Metcalfe C, Wallis C, et al. Assessing the usefulness of outcomes measured in a cystic fibrosis treatment trial. Respir Med 2007;101:254–260. | Evaluating terminal outcomes after an intervention
Thomas C, Mitchell P, O’Rourke P, et al. Quality-of-life in children and adolescents with cystic fibrosis managed in both regional outreach and cystic fibrosis center settings in Queensland. J Pediatr 2006;148:508–516. | Not evaluating the link between intermediate outcomes and important health outcomes
Venuta F, Rendina EA, Rocca GD, et al. Pulmonary hemodynamics contribute to indicate priority for lung transplantation in patients with cystic fibrosis. J Thorac Cardiovasc Surg 2000;119:682–689. | Not evaluating the link between intermediate outcomes and important health outcomes
Wahl AK, Rustoen T, Hanestad BR, et al. Living with cystic fibrosis: Impact on global quality of life. Heart Lung 2005;34:324–331. | Not evaluating the link between intermediate outcomes and important health outcomes
Waterhouse DF, McLaughlin AM, Gallagher CG. Time course and recovery of arterial blood gases during exacerbations in adults with cystic fibrosis. J Cyst Fibros 2009;8:9–13. | Not evaluating the link between intermediate outcomes and important health outcomes
Watts KD, Seshadri R, Sullivan C, et al. Increased prevalence of risk factors for morbidity and mortality in the US hispanic CF population. Pediatr Pulmonol 2009;44:594–601. | Not evaluating the link between intermediate outcomes and important health outcomes

Legend: CF=cystic fibrosis

Excluded Studies from Full-Text Review of Key Question 5 Search

Reference | Reason for Exclusion
Abs R, Bengtsson BA, Hernberg-Stahl E, et al. GH replacement in 1034 growth hormone deficient hypopituitary adults: Demographic and clinical characteristics, dosing and safety. Clin Endocrinol (Oxford) 1999;50:703–713. | Not evaluating malignancy outcomes
Abs R, Mattsson AF, Bengtsson BA, et al. Isolated growth hormone (GH) deficiency in adult patients: Baseline clinical characteristics and responses to GH replacement in comparison with hypopituitary patients. A sub-analysis of the KIMS database. Growth Horm IGF Res 2005;15:349–359. | Not evaluating malignancy outcomes
Ahmad AM, Guzder R, Wallace AM, et al. Circadian and ultradian rhythm and leptin pulsatility in adult GH deficiency: Effects of GH replacement. J Clin Endocrinol Metab 2001;86:3499–3506. | Not in CF, ISS, or GHD patients
Ahmad AM, Hopkins MT, Thomas J, et al. Body composition and quality of life in adults with growth hormone deficiency; effects of low-dose growth hormone replacement. Clin Endocrinol (Oxford) 2001;54:709–717. | Not in CF, ISS, or GHD patients
Ahmad AM, Hopkins MT, Weston PJ, et al. Effects of GH replacement on 24-h ambulatory blood pressure and its circadian rhythm in adult GH deficiency. Clin Endocrinol (Oxford) 2002;56:431–437. | Not in CF, ISS, or GHD patients
Andiran N, Yordam N. TNF-alpha levels in children with growth hormone deficiency and the effect of long-term growth hormone replacement therapy. Growth Horm IGF Res 2007;17:149–153. | Not evaluating malignancy outcomes
Bozzola M, De Amici M, Zecca M, et al. Modulating effect of human growth hormone on tumour necrosis factor-alpha and interleukin-1beta. Eur J Endocrinol 1998;138:640–643. | Not evaluating malignancy outcomes
Brandou F, Aloulou I, Razimbaud A, et al. Lower ability to oxidize lipids in adult patients with growth hormone (GH) deficiency: Reversal under GH treatment. Clin Endocrinol (Oxf) 2006;65:423- 428. | Not in CF, ISS, or GHD patients
Buchanan CR, Preece MA, Milner RD. Mortality, neoplasia, and creutzfeldt-jakob disease in patients treated with human pituitary growth hormone in the United Kingdom. BMJ 1991;302:824–828. | Not in CF, ISS, or GHD patients
Butenandt O, Jocham A, Schwarz HP, et al. Childhood onset of GH deficiency: Reassessment of GH status and effects of substitution. Growth Horm IGF Res 1998;8:9–13. | Not evaluating malignancy outcomes
Carmona M, Jordan J, Fernandez F, et al. Growth retardation, GH deficiency, hyperprolactinemia and delayed puberty. An Esp Pediatr 1985;22:397–401. | Not evaluating malignancy outcomes
Colao A, Di Somma C, Spiezia S, et al. Effect of growth hormone (GH) and/or testosterone replacement on the prostate in GH-deficient adult patients. J Clin Endocrinol Metab 2003;88:88–94. | Not in CF, ISS, or GHD patients
Feldt-Rasmussen U, Wilton P, Jonsson P, et al. Aspects of growth hormone deficiency and replacement in elderly hypopituitary adults. Growth Horm IGF Res 2004;14:S51–S58. | Not in CF, ISS, or GHD patients
Fernholm R, Bramnert M, Hagg E, et al. Growth hormone replacement therapy improves body composition and increases bone metabolism in elderly patients with pituitary disease. J Clin Endocrinol Metab 2000;85:4104–4112. | Not in CF, ISS, or GHD patients
Finkenstedt G, Hofle G, Pallua A, et al. Changes in the volume of residual pituitary adenomas in patients with adult-onset growth hormone deficiency during replacement therapy with the recombinant human growth hormone. Wien Klin Wochenschr 1999;111:887–890. | Not in CF, ISS, or GHD patients
Fradkin JE, Mills JL, Schonberger LB, et al. Risk of leukemia after treatment with pituitary growth hormone. JAMA 1993;270:2829–2832. | Not in CF, ISS, or GHD patients
Hatrick AG, Boghalo P, Bingham JB, et al. Does GH replacement therapy in adult GH-deficient patients result in recurrence or increase in size of pituitary tumours?. Eur J Endocrinol 2002;146:807–811. | Not in CF, ISS, or GHD patients
Hilczer M, Smyczynska J, Stawerska R, et al. Final height and growth hormone secretion after completion of growth hormone therapy in patients with idiopathic growth hormone deficiency and with abnormalities of the hypothalamic-pituitary region. Neuroendocrinol Lett 2005;26:19–24. | Not evaluating malignancy outcomes
Hoybye C, Jonsson P, Monson JP, et al. Impact of the primary aetiology upon the clinical outcome of adults with childhood-onset GH deficiency. Eur J Endocrinol 2007;157:589–596. | Not evaluating malignancy outcomes
Kaplowitz PB, Rundle AC, Blethen SL. Weight relative to height before and during growth hormone therapy in prepubertal children. Horm Metab Res 1998;30:565–569. | Not evaluating malignancy outcomes
Koranyi J, Bosaeus I, Alpsten M, et al. Body composition during GH replacement in adults methodological variations with respect to gender. Eur J Endocrinol 2006;154:545–553. | Not in CF, ISS, or GHD patients
Lanes R, Paoli M, Carrillo E, et al. Peripheral inflammatory and fibrinolytic markers in adolescents with growth hormone deficiency: Relation to postprandial dyslipidemia. J Pediatr 2004;145:657–661. | Not in CF, ISS, or GHD patients
le Roux CW, Jenkins PJ, Chew SL, et al. Growth hormone replacement does not increase serum prostate-specific antigen in hypopituitary men over 50 years. Eur J Endocrinol 2002;147:59–63. | Not in CF, ISS, or GHD patients
Mills JL, Schonberger LB, Wysowski DK, et al. Long-term mortality in the United States cohort of pituitary-derived growth hormone recipients. J Pediatr 2004;144:430–436. | Not evaluating use of rhGH
Milner RD, Preece MA, Tanner JM. Growth in height compared with advancement in skeletal maturity in patients treated with human growth hormone. Arch Dis Child 1980;55:461–466. | Not evaluating malignancy outcomes
Pagani S, Meazza C, Travaglino P, et al. Serum cytokine levels in GH-deficient children during substitutive GH therapy. Eur J Endocrinol 2005;152:207–210. | Not evaluating malignancy outcomes
Pincelli AI, Brunani A, Scacchi M, et al. The serum concentration of tumor necrosis factor alpha is not an index of growth-hormone- or obesity-induced insulin resistance. Horm Res 2001;55:57–64. | Not in CF, ISS, or GHD patients
Price DA, Ranke MB, Guilbaud O. Growth response in the first year of growth hormone treatment in prepubertal children with organic growth hormone deficiency: A comparison with idiopathic growth hormone deficiency. the executive scientific committee of the kabi international growth study. Acta Paediatr Scand Suppl 1990;370:131–137. | Not evaluating malignancy outcomes
Rosenfalck AM, Fisker S, Hilsted J, et al. The effect of the deterioration of insulin sensitivity on -cell function in growth- hormone-deficient adults following 4-month growth hormone replacement therapy. Growth Horm IGF Res 1999;9:96–105. | Not in CF, ISS, or GHD patients
Schneider HJ, Oertel H, Murck H, et al. Night sleep EEG and daytime sleep propensity in adult hypopituitary patients with growth hormone deficiency before and after six months of growth hormone replacement. Psychoneuroendocrinology 2005;30:29–37. | Not in CF, ISS, or GHD patients
Scire G, Del Bianco C, Spadoni GL, et al. Growth hormone therapy does not alter the insulin-like growth factor-I/insulin-like growth factor binding protein-3 molar ratio in growth hormone-deficient children. J Endocrinol Invest 2008;31:153–158. | Not evaluating malignancy outcomes
Serri O, St-Jacques P, Sartippour M, et al. Alterations of monocyte function in patients with growth hormone (GH) deficiency: Effect of substitutive GH therapy. J Clin Endocrinol Metab 1999;84:58–63. | Not in CF, ISS, or GHD patients
Sheppard L, Eiser C, Davies HA, et al. The effects of growth hormone treatment on health-related quality of life in children. Horm Res 2006;65:243–249. | Not in CF, ISS, or GHD patients
Slyper A. The safety and effectiveness of human growth hormone using pharmacological dosing. Med Hypotheses 1995;45:523–528. | Not a report of a new discovery
Sneppen SB, Steensgaard-Hansen F, Feldt-Rasmussen U. Cardiac effects of low-dose growth hormone replacement therapy in growth hormone-deficient adults. an 18-month randomised, placebo- controlled, double-blind study. Horm Res 2002;58:21–29. | Not in CF, ISS, or GHD patients
Sorgo W, Zachmann M, Tassinari D, et al. Longitudinal anthropometric measurements in patients with growth hormone deficiency. effect of human growth hormone treatment. Eur J Pediatr 1982;138:38–45. | Not evaluating malignancy outcomes
Steinhausen HC, Dorr HG, Malin Z. Behavioral evaluation of GH treatment in short statured children and adolescents: Findings from a pilot study. J Endocrinol Invest 2002;25:351–356. | Not evaluating malignancy outcomes
Ten Have SM, van der Lely AJ, Lamberts SW. Increase in haemoglobin concentrations in growth hormone deficient adults during human recombinant growth hormone replacement therapy. Clin Endocrinol (Oxford) 1997;47:565–570. | Not in CF, ISS, or GHD patients
Ueland T, Bollerslev J, Flyvbjerg A, et al. Effects of 12 months of GH treatment on cortical and trabecular bone content of IGFs and OPG in adults with acquired GH deficiency: A double-blind, randomized, placebo-controlled study. J Clin Endocrinol Metab 2002;87:2760–1763. | Not in CF, ISS, or GHD patients
Ueland T, Odgren PR, Yndestad A, et al. Growth hormone substitution increases gene expression of members of the IGF family in cortical bone from women with adult onset growth hormone deficiency--relationship with bone turn-over. Bone 2003;33:638–645. | Not in CF, ISS, or GHD patients
Wilhelm B, Kann PH. Long-term effects of 7-year growth hormone substitution on bone metabolism, bone density, and bone quality in growth hormone-deficient adults. Med Klin 2004;99:569–577. | Not evaluating malignancy outcomes
Wyatt D. Lessons from the national cooperative growth study. Eur J Endocrinol 2004;151:S55–9. | Not evaluating malignancy outcomes
Xu W, Janss A, Moshang T. Adult height and adult sitting height in childhood medulloblastoma survivors. J Clin Endocrinol Metab 2003;88:4677–4681. | Not in CF, ISS, or GHD patients
Zvulunov A, Wyatt DT, Laud PW, et al. Lack of effect of growth hormone therapy on the count and density of melanocytic naevi in children. Br J Dermatol 1997;137:545–548. | Not in CF, ISS, or GHD patients

Legend: CF=cystic fibrosis; GHD=growth hormone deficient; IGF=insulin-like growth factor; IGFBP=insulin-like growth factor-binding protein; ISS=idiopathic short stature; rhGH=recombinant human growth hormone