# Data Extraction Forms

Trials Evaluating rhGH in Patients With Cystic Fibrosis

Linkages of Intermediate Outcomes to Important Health Outcomes

Malignant Harms