# Search Strategies

Number of citations in ()
/ after an index term indicates that all subheadings were selected.
* before an index term indicates that that term was focused - i.e. limited to records where major MeSH/Emtree term.
“exp” before an index term indicates that the term was exploded.
.tw. indicates a search for a term in title/abstract.
.mp. indicates a free text search for a term.
.pt. indicates a search for a publication type.
$ at the end of a term indicates that this term has been truncated.
? in the middle of a term indicates the use of a wildcard.
adj indicates a search for two terms where they appear adjacent to one another.
sh indicates a search term for subheading.

## Key Questions 1, 2, 4, 6, and 7 Search

### MEDLINE (Ovid)

1. Cystic Fibrosis/
2. cystic fibrosis.mp.
3. 1 or 2
4. Human Growth Hormone/
5. human growth hormone.mp.
6. recombinant human growth hormone.mp.
7. rhgh.mp.
8. hgh.mp.
9. somatropin.mp.
10. genotropin.mp.
11. humatrope.mp.
12. hypertropin.mp.
13. jintropin.mp.
14. nordotropin.mp.
15. nutropin.mp.
16. omnitrope.mp
17. saizen.mp.
18. serostim.mp.
19. zomacton.mp.
20. zorbtive.mp.
21. crytropin.mp.
22. Or/ 4 – 21
23. 3 and 22

### Central (Ovid)

1. Cystic Fibrosis/
2. cystic fibrosis.mp.
3. 1 or 2
4. Human Growth Hormone/
5. human growth hormone.mp.
6. recombinant human growth hormone.mp.
7. rhgh.mp.
8. hgh.mp.
9. somatropin.mp.
10. genotropin.mp.
11. humatrope.mp.
12. hypertropin.mp.
13. jintropin.mp.
14. nordotropin.mp.
15. nutropin.mp.
16. omnitrope.mp
17. saizen.mp.
18. serostim.mp.
19. zomacton.mp.
20. zorbtive.mp.
21. crytropin.mp.
22. Or/ 4 – 21
23. 3 and 22

## Key Question 3 Search

### MEDLINE (Ovid)

1. Epidemiologic studies/
2. Exp case control studies/
3. Exp Cohort Studies/
4. Case control.tw.
5. (cohort adj (study or studies)).tw.
6. cohort analy$.tw.
7. (follow up adj (study or studies)).tw.
8. (observational adj (study or studies)).tw.
9. longitudinal.tw.
10. retrospective.tw.
11. cross sectional.tw.
12. Cross-Sectional Studies/
13. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12
14. randomized controlled trial.pt.
15. controlled clinical trial.pt.
16. randomized.ab.
17. placebo.ab.
18. drug therapy.fs.
19. randomly.ab.
20. trial.ab.
21. groups.ab.
22. 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21
23. animals.sh not (humans.sh. and animals.sh.)
24. 22 not 23
25. 13 or 24
26. Cystic Fibrosis/
27. cystic fibrosis.mp.
28. 26 or 27
29. Mortality/
30. mortality.mp.
31. death.mp.
32. Quality of Life/
33. $quality of life.mp.
34. $qol.mp.
35. Fractures, Bone/
36. bone fracture$.mp.
37. broken bones.mp.
38. Neoplasms/
39. neoplas$.mp.
40. malignan$.mp.
41. cancer.mp.
42. tumor.mp.
43. Or/ 29 – 42
44. 25 and 28 and 43

### Central (Ovid)

1. Cystic Fibrosis/
2. cystic fibrosis.mp.
3. 1 or 2
4. Mortality/
5. mortality.mp.
6. death.mp.
7. Quality of Life/
8. $quality of life.mp.
9. $qol.mp.
10. Fractures, Bone/
11. bone fracture$.mp.
12. broken bones.mp.
13. Neoplasms/
14. neoplas$.mp.
15. malignan$.mp.
16. cancer.mp.
17. tumor.mp.
18. Or/ 4 – 17
19. 3 and 18

## Key Question 5 Search

### MEDLINE (Ovid)

1. Epidemiologic studies/
2. Exp case control studies/
3. Exp Cohort Studies/
4. Case control.tw.
5. (cohort adj (study or studies)).tw.
6. cohort analy$.tw.
7. (follow up adj (study or studies)).tw.
8. (observational adj (study or studies)).tw.
9. longitudinal.tw.
10. retrospective.tw.
11. cross sectional.tw.
12. Cross-Sectional Studies/
13. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12
14. randomized controlled trial.pt.
15. controlled clinical trial.pt.
16. randomized.ab.
17. placebo.ab.
18. drug therapy.fs.
19. randomly.ab.
20. trial.ab.
21. groups.ab.
22. 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21
23. animals.sh not (humans.sh. and animals.sh.)
24. 22 not 23
25. 13 or 24
26. Human Growth Hormone/
27. human growth hormone.mp.
28. recombinant human growth hormone.mp.
29. rhgh.mp.
30. hgh.mp.
31. somatropin.mp.
32. genotropin.mp.
33. humatrope.mp.
34. hypertropin.mp.
35. jintropin.mp.
36. nordotropin.mp.
37. nutropin.mp.
38. omnitrope.mp
39. saizen.mp.
40. serostim.mp.
41. zomacton.mp.
42. zorbtive.mp.
43. crytropin.mp.
44. Or/ 26 – 43
45. Neoplasms/
46. neoplas$.mp.
47. malignan$.mp.
48. cancer.mp.
49. tumor.mp.
50. Or/ 45 – 49
51. idiopathic short stature.mp.
52. ISS.mp.
53. growth hormone deficiency.mp.
54. GHD.mp.
55. GH deficiency.mp.
56. Or/ 51 – 55
57. 25 and 44 and 50 and 56

### Central (Ovid)

1. Human Growth Hormone/
2. human growth hormone.mp.
3. recombinant human growth hormone.mp.
4. rhgh.mp.
5. hgh.mp.
6. somatropin.mp.
7. genotropin.mp.
8. humatrope.mp.
9. hypertropin.mp.
10. jintropin.mp.
11. nordotropin.mp.
12. nutropin.mp.
13. omnitrope.mp
14. saizen.mp.
15. serostim.mp.
16. zomacton.mp.
17. zorbtive.mp.
18. crytropin.mp.
19. Or/ 1 – 18
20. Neoplasms/
21. neoplas$.mp.
22. malignan$.mp.
23. cancer.mp.
24. tumor.mp.
25. Or/ 20 – 24
26. idiopathic short stature.mp.
27. ISS.mp.
28. growth hormone deficiency.mp.
29. GHD.mp.
30. GH deficiency.mp.
31. Or/ 26 – 30
32. 19 and 25 and 31