# Apppendixes

Appendix A Search Strategies

Appendix B Data Extraction Forms

Appendix C Excluded Studies from Searches

Appendix D Glossary

Appendix E Abbreviations

Appendix F Additional Evidence Tables