# AHRQ Contacts

Stephanie Chang, M.D., M.P.H.

Director, Evidence-based Practice Center Program

Agency for Healthcare Research and Quality

Rockville, MD

Carmen Kelly, Pharm.D., M.P.H., R.Ph.

Task Order Officer, Evidence-based Practice Center Program

Agency for Healthcare Research and Quality

Rockville, MD