# Acknowledgments

The Evidence-based Practice Center thanks Ajibade Ashaye for his valuable contribution to this project. We are indebted to the following investigators who provided us additional information or clarification on their clinical trials: Dana S. Hardin, M.D.; Mario G. Bianchetti, M.D.; and Dominique Darmaun, MD. We appreciate their willingness to provide us with the information we needed