# References

1 Crusher RH. Rotator cuff injuries. Accident & Emergency Nursing. 2000;8(3):129-133. [pmid: 10893553].
2 Bartolozzi A, Andreychik D, Ahmad S. Determinants of outcome in the treatment of rotator cuff disease. Clin Orthop Related Res. 1994:90-97.
3 Ghodadra NS, Provencher MT, Verma NN, et al. Open, mini-open and all-arthroscopic rotator cuff repair surgery: indications and implications for rehabilitations. J Orthop Sporsts Phys Ther. 2009;39:81-89.
4 Suenaga N, Minami A, Kaneda K. Postoperative subcoracoid impingement syndrome in patients with rotator cuff tear. J Shoulder Elbow Surg. 2000;9(4):275-278. [pmid: 10979521].
5 Wittenberg RH, Rubenthaler F, Wolk T, et al. Surgical or conservative treatment for chronic rotator cuff calcifying tendinitis—a matched-pair analysis of 100 patients. Arch Orthop Trauma Surg. 2001;121(1–2):56-59. [pmid: 11195119].
6 Fukuda H. The management of partial thickness tears of the rotator cuff. J Bone Joint Surg Br. 2003;85(1):3-11. [pmid: 12585570].
7 Gerber C, Fuchs B, Hodler J. The results of repair of massive tears of the rotator cuff. J Bone Joint Surg Am. 2000;82(4):505-515. [pmid: 10761941].
8 Favard L, Bacle G, Berhouet J. Rotator cuff repair. Joint Bone Spine. 2007;74(6):551-557. [pmid: 17993287].
9 Gomoll AH, Katz JN, Warner JJP, et al. Rotator cuff disorders - Recognition and management among patients with shoulder pain. Arthritis and Rheumatism. 2004;50(12):3751-3761. [pmid: 15593187].
10 Yamaguchi K, Tetro AM, Blam O, et al. Natural history of asymptomatic rotator cuff tears: a longitudinal analysis of asymptomatic tears detected sonographically. J Shoulder Elbow Surg. 2001;10:199-203. [pmid: 11408898].
11 Snyder SJ, Tomlinson RJ. Arthroscopic evaluation and treatment of rotator cuff disease. Hand and Upper Extremity. 1997:87-105.
12 Coghlan JA, Buchbinder R, Green S, et al. Surgery for rotator cuff disease [Systematic Review]. Cochrane Database Syst Rev. 2008;(1):CD005619.
13 Lin JC, Weintraub N, Aragaki DR. Nonsurgical treatment for rotator cuff injury in the elderly. Journal of the American Medical Directors Association. 2008;9(9):626-632. [pmid: 18992694].
14 Zakaria D. Rates of carpal tunnel syndrome, epicondylitis, and rotator cuff claims in Ontario workers during 1997. Chronic Dis Can. 2004;25:3239.
15 Zakaria D, Robertson J, MacDermid JC, et al. Estimating the population at risk for Ontario Workplace Safety and Insurance Board-covered injuries or diseases. Chronic Dis Can. 2002;23:1721.
16 Herberts P, Kadefors R, Hogfors C, et al. Shoulder pain and heavy manual labor. Clin Orthop Relat Res. 1984:166-178.
17 Bureau of Labor Statistics. Nonfatal occupational injuries and illnesses requiring days away from work, 2007. United States Department of Labor. 2008. Available at: http://www.bls.gov/news.release/pdf/osh2.pdf. Accessed January 25, 2010.
18 MacDermid JC, Ramos J, Drosdowech D, et al. The impact of rotator cuff pathology on isometric and isokinetic strength, function, and quality of life. Journal of Shoulder and Elbow Surgery. 2004:593-598.
19 Burbank KM, Stevenson JH, Czarnecki GR, et al. Chronic shoulder pain: Part I. Evaluation and diagnosis. American Family Physician. 2008;77(4):453-460. [pmid: 18326164].
20 Hughes PC, Taylor NF, Green RA. Most clinical tests cannot accurately diagnose rotator cuff pathology: a systematic review. Australian Journal of Physiotherapy. 2008;54(3):159-170. [pmid: 18721119].
21 Bryant L, Shnier R, Bryant C, et al. A comparison of clinical estimation, ultrasonography, magnetic resonance imaging, and arthroscopy in determining the size of rotator cuff tears. J Shoulder Elbow Surg. 2002;11(3):219-224. [pmid: 12070492].
22 Oh LS, Wolf BR, Hall MP, et al. Indications for rotator cuff repair: A systematic review. Clinical Orthopaedics and Related Research. 2007:52-63.
23 Burbank KM, Stevenson JH, Czarnecki GR, et al. Chronic shoulder pain: Part II. Treatment. American Family Physician. 2008;77(4):493-497. [pmid: 18326169].
24 Noerdlinger MA, Fadale PD. The role of injectable corticosteroids in orthopedics. Orthopedics. 2001;24(4):400-405. [pmid: 11332971].
25 Nho S, Michael JS. American Academy of Orthopaedic Surgeons RIUSS. Systematic review of arthroscopic rotator cuff repair and mini-open rotator cuff repair. American Academy of Orthopaedic Surgeons, San Diego, February 14–18, 2007. Journal of Bone and Joint Surgery Am. 2007;89A(Suppl 3):127-136.
26 Iannotti JP, Codsi MJ, Lafosse L, et al. Management of rotator cuff disease: intact and repairable cuff. Iannotti JP, Williams GR Jr, editors. Disorders of the shoulder: diagnosis and management. 2nd ed. Philadelphia, PA. Lippincott Williams & Wilkins. 2007:53-100.
27 Matsen FA III, Arntz CT, Lippitt SB. Rotator cuff 14037. Rockwood CA Jr, Matsen FA III, editors. The Shoulder. 2nd ed. Philadelphia, PA. W.B. Saunders Brace & Company. 1998:755-839.
28 Hollinshead RM, Mohtadi NG, Vande Guchte RA, et al. Two 6-year follow-up studies of large and massive rotator cuff tears: comparison of outcome measures. J Shoulder Elbow Surg. 2000;9(5):373-381. [pmid: 11075319].
29 Razmjou H, Bean A, van VO, et al. Cross-sectional and longitudinal construct validity of two rotator cuff disease-specific outcome measures. BMC Musculoskeletal Disorders. 2006;7:26. [pmid: 16533405].
30 Ware JE Jr. SF-36 health survey update. Spine. 2000;25(24):3130-3139. [pmid: 11124729].
31 Beaton DE, Richards RR. Measuring function of the shoulder. A cross-sectional comparison of five questionnaires. J Bone Joint Surg Am. 1996;78(6):882-890. [pmid: 8666606].
32 MacDermid JC, Drosdowech D, Faber K. Responsiveness of self-report scales in patients recovering from rotator cuff surgery. J Shoulder Elbow Surg. 2006;15(4):407-414. [pmid: 16831642].
33 Kirkley A, Alvarez C, Griffin S. The development and evaluation of a disease-specific quality-of-life questionnaire for disorders of the rotator cuff: The Western Ontario Rotator Cuff Index. Clin J Sport Med. 2003;13(2):84-92. [pmid: 12629425].
34 Beaton DE, Schemitsch E. Measures of health-related quality of life and physical function. Clinical Orthopaedics and Related Research. 2003:90-105.
35 Hudak PL, Amadio PC, Bombardier C. Development of an upper extremity outcome measure: the DASH (disabilities of the arm, shoulder and hand) [corrected]. The Upper Extremity Collaborative Group (UECG). Am J Ind Med. 1996;29(6):602-608. [pmid: 8773720].
36 Roy JS, MacDermid JC, Woodhouse LJ. Measuring shoulder function: a systematic review of four questionnaires. Arthritis Rheum. 2009;61(5):623-632. [pmid: 19405008].
37 L‘Insalata JC, Warren RF, Cohen SB, et al. A self-administered questionnaire for assessment of symptoms and function of the shoulder. J Bone Joint Surg Am. 1997;79(5):738-748. [pmid: 9160947].
38 Paul A, Lewis M, Shadforth MF, et al. A comparison of four shoulder-specific questionnaires in primary care. Ann Rheum Dis. 2004;63(10):1293-1299. [pmid: 15361390].
39 Lippitt SB, Harryman DT II, Matsen FA III. A practical tool for evaluation function: the simple shoulder test The Shoulder: A Balance of Mobility and Stability. Matsem FA III, Fu FH, Hawkins RJ, editors. Rosemont, IL. American Academy of Orthopaedic Surgeons. 1993:545-559.
40 Roddey TS, Olson SL, Cook KF, et al. Comparison of the University of California-Los Angeles Shoulder Scale and the Simple Shoulder Test with the shoulder pain and disability index: single-administration reliability and validity. Phys Ther. 2000;80(8):759-768. [pmid: 10911414].
41 MacDermid JC, Solomon P, Prkachin K. The shoulder pain and disability index demonstrates factor, construct and longitudinal validity. BMC Musculoskeltetal Disorders. 2006;7(12).
42 Roach KE, Budiman-Mak E, Songsiridej N, et al. Development of a shoulder pain and disability index. Arthritis Care & Research. 1991;4(4):143-149. [pmid: 11188601].
43 Kocher MS, Horan MP, Briggs KK, et al. Reliability, validity, and responsiveness of the American Shoulder and Elbow Surgeons subjective shoulder scale in patients with shoulder instability, rotator cuff disease, and glenohumeral arthritis. J Bone Joint Surg Am. 2005;87(9):2006-2011. [pmid: 16140816].
44 Richards RR, An KN, Bigliani LU, et al. A standardized method for the assessment of shoulder function. J Shoulder Elbow Surg. 1994;3:347-352.
45 Michener LA, McClure PW, Sennett BJ. American Shoulder and Elbow Surgeons Standardized Shoulder Assessment Form, patient self-report section: reliability, validity, and responsiveness. J Shoulder Elbow Surg. 2002;11(6):587-594. [pmid: 12469084].
46 Amstutz HC, Sew Hoy AL, Clarke IC. UCLA anatomic total shoulder arthroplasty. Clin Orthop. 1981;155:10-14.
47 Romeo AA, Mazzocca A, Hang DW, et al. Shoulder scoring scales for the evaluation of rotator cuff repair. Clin Orthop Related Res. 2004:107-114.
48 Cook KF, Roddey TS, Olson SL, et al. Reliability by surgical status of self-reported outcomes in patients who have shoulder pathologies. J Orthop Sports Phys Ther. 2002;32(7):336-346. [pmid: 12113468].
49 Leggin BG, Michener LA, Shaffer MA, et al. The Penn Shoulder Score: Reliability and validity. Journal of Orthopaedic and Sports Physical Therapy. 2006:138-151.
50 Higgins J, Green SE. Cochrane Handbook for Systematic Reviews of Interventions Version 5.0.1 [updated September 2008]. The Cochrane Collaboration. 2008.
51 Cho M, Bero L. The quality of drug studies published in symposium proceedings. Ann Int Med. 1996;124:185-189.
52 Lewis J, Machin D. Intention to treat - who should use ITT?. Br J Cancer. 1993;68(4):647-650. [pmid: 8398686].
53 Newell D. Intention-to-treat analysis: implications for quantitative and qualitative research. Int J Epidemiol. 1992;21:837-841. [pmid: 1468842].
54 Wells G, Shea B, O‘Connell B, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomized studies in meta-analyses. Department of Epidemiology and Community Medicine, University of Ottawa. 2009.
55 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: Grading the strength of a body of evidence when comparing medical interventions–Agency for Healthcare Research and Quality and the Effective Health-care Program. J Clin Epi. 2010;63(5):513-523.
56 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. BMJ. 2004;328(7454):1490. [pmid: 15205295].
57 Tashjian RZ, Deloach J, Porucznik CA, et al. Minimal clinically important differences (MCID) and patient acceptable symptomatic state (PASS) for visual analog scales (VAS) measuring pain in patients treated for rotator cuff disease. J Shoulder Elbow Surg. 2009;18(6):927-932. [pmid: 19535272].
58 Higgins JPT, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539. [pmid: 12111919].
59 Deeks JJ, Altman DG, Bradburn MJ. Statistical methods for examining heterogeneity and combining results from several studies in meta-analysis. Egger M, Davey Smith G, Altman DG, editors. Systematic review in health care: meta-analysis in context. Second edition. London. BMJ Publishing Group. 2001:285-312.
60 Iannotti JP, Bernot MP, Kuhlman JR, et al. Postoperative assessment of shoulder function: a prospective study of full-thickness rotator cuff tears. J Shoulder Elbow Surg. 1996;5(6):449-457. [pmid: 8981270].
61 Galatz LM, Griggs S, Cameron BD, et al. Prospective longitudinal analysis of postoperative shoulder function: a ten-year follow-up study of full-thickness rotator cuff tears. J Bone Joint Surg Am. 2001;83-A(7):1052-1056. [pmid: 11451975].
62 Bennett WF. Arthroscopic repair of massive rotator cuff tears: a prospective cohort with 2- to 4-year follow-up. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2003;19(4):380-390.
63 Klinger HM, Spahn G, Baums MH, et al. Arthroscopic debridement of irreparable massive rotator cuff tears—a comparison of debridement alone and combined procedure with biceps tenotomy. Acta Chirurgica Belgica. 2005;105(3):297-301. [pmid: 16018524].
64 Bennett WF. Arthroscopic repair of anterosuperior (supraspinatus/subscapularis) rotator cuff tears: a prospective cohort with 2- to 4-year follow-up. Classification of biceps subluxation/instability. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2003;19(1):21-33.
65 Klinger HM, Steckel H, Ernstberger T, et al. Arthroscopic debridement of massive rotator cuff tears: negative prognostic factors. Arch Orthop Trauma Surg. 2005;125(4):261-266. [pmid: 15378320].
66 Moosmayer S, Lund G, Seljom U, et al. Comparison between surgery and physiotherapy in the treatment of small and medium-sized tears of the rotator cuff: a randomised controlled study of 103 patients with one-year followup. J Bone Joint Surg Br. 2010;92(1):83-91. [pmid: 20044684].
67 Audenaert E, Van NJ, Schepens A, et al. Reconstruction of massive rotator cuff lesions with a synthetic interposition graft: a prospective study of 41 patients. Knee Surg Sports Traumatol Arthrosc. 2006;14(4):360-364. [pmid: 16252125].
68 Baker CL, Liu SH. Comparison of open and arthroscopically assisted rotator cuff repairs. Am J Sports Med. 1995;23(1):99-104. [pmid: 7726359].
69 Baysal D, Balyk R, Otto D, et al. Functional outcome and health-related quality of life after surgical repair of full-thickness rotator cuff tear using a mini-open technique. Am J Sports Med. 2005;33(9):1346-1355. [pmid: 16002486].
70 Bennett WF. Arthroscopic repair of full-thickness supraspinatus tears (small-to-medium): A prospective study with 2- to 4-year follow-up. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2003;19(3):249-256.
71 Bigoni M, Gorla M, Guerrasio S, et al. Shoulder evaluation with isokinetic strength testing after arthroscopic rotator cuff repairs. J Shoulder Elbow Surg. 2009;18(2):178-183. [pmid: 19111477].
72 Bishop J, Klepps S, Lo IK, et al. Cuff integrity after arthroscopic vs. open rotator cuff repair: a prospective study. J Shoulder Elbow Surg. 2006;15(3):290-299. [pmid: 16679227].
73 Boehm TD, Werner A, Radtke S, et al. The effect of suture materials and techniques on the outcome of repair of the rotator cuff: a prospective, randomised study. J Bone Joint Surg Br. 2005;87(6):819-823. [pmid: 15911666].
74 Boileau P, Brassart N, Watkinson DJ, et al. Arthroscopic repair of full-thickness tears of the supraspinatus: does the tendon really heal?. J Bone Joint Surg Am. 2005;87(6):1229-1240. [pmid: 15930531].
75 Boileau P, Baque F, Valerio L, et al. Isolated arthroscopic biceps tenotomy or tenodesis improves symptoms in patients with massive irreparable rotator cuff tears. J Bone Joint Surg Am. 2007;89(4):747-757. [pmid: 17403796].
76 Boszotta H, Prunner K. Arthroscopically assisted rotator cuff repair. [Review] [21 refs]. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2004;20(6):620-626.
77 Buess E, Steuber KU, Waibl B. Open vs. arthroscopic rotator cuff repair: a comparative view of 96 cases. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2005;21(5):597-604.
78 Burks RT, Crim J, Brown N, et al. A prospective randomized clinical trial comparing arthroscopic single- and double-row rotator cuff repair: magnetic resonance imaging and early clinical evaluation. Am J Sports Med. 2009;37(4):674-682. [pmid: 19204365].
79 Caniggia M, Maniscalco P, Pagliantini L, et al. Titanium anchors for the repair of rotator cuff tears: preliminary report of a surgical technique. J Orthop Trauma. 1995;9(4):312-317. [pmid: 7562153].
80 Charousset C, Grimberg J, Duranthon LD, et al. The time for functional recovery after arthroscopic rotator cuff repair: correlation with tendon healing controlled by computed tomography arthrography. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2008;24(1):25-33.
81 Charousset C, Grimberg J, Duranthon LD, et al. Can a double-row anchorage technique improve tendon healing in arthroscopic rotator cuff repair?: A prospective, nonrandomized, comparative study of double-row and single-row anchorage techniques with computed tomographic arthrography tendon healing assessment. Am J Sports Med. 2007;35(8):1247-1253. [pmid: 17452513].
82 Checchia SL, Doneux PS, Miyazaki AN, et al. Biceps tenodesis associated with arthroscopic repair of rotator cuff tears. J Shoulder Elbow Surg. 2005;14(2):138-144. [pmid: 15789006].
83 Cofield RH, Parvizi J, Hoffmeyer PJ, et al. Surgical repair of chronic rotator cuff tears. A prospective long-term study. J Bone Joint Surg Am. 2001;83-A(1):71-77. [pmid: 11205861].
84 Cole BJ, McCarty LP III, Kang RW, et al. Arthroscopic rotator cuff repair: prospective functional outcome and repair integrity at minimum 2-year follow-up. J Shoulder Elbow Surg. 2007;16(5):579-585. [pmid: 17629505].
85 Colegate-Stone T, Allom R, Tavakkolizadeh A, et al. An analysis of outcome of arthroscopic vs. mini-open rotator cuff repair using subjective and objective scoring tools. Knee Surg Sports Traumatol Arthrosc. 2009;17(6):691-694. [pmid: 19002667].
86 Cools A, Declercq G, Sneyers C, et al. Isokinetic muscle strength and functional restoration following surgical repair of the rotator cuff: A prospective study. Isokinetics and Exercise Science. 2006:291-300.
87 Costouros JG, von Campe A, Gerber C. Arthroscopic Rotator Cuff Repair Leads to Less Postoperative Fatty Infiltration than Open Repair. 20th Congress of the European Society for Surgery of the Shoulder and the Elbow (SECEC-ESSSE 2006). Athens, Se. 2006:20-23.
88 Cummins CA, Strickland S, Appleyard RC, et al. Rotator cuff repair with bioabsorbable screws: An in vivo and ex vivo investigation. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2003;19(3):239-248.
89 Davidson PA, Rivenburgh DW. Rotator cuff repair tension as a determinant of functional outcome. J Shoulder Elbow Surg. 2000;9(6):502-506. [pmid: 11155303].
90 DeFranco MJ, Bershadsky B, Ciccone J, et al. Functional outcome of arthroscopic rotator cuff repairs: a correlation of anatomic and clinical results. J Shoulder Elbow Surg. 2007;16(6):759-765. [pmid: 18061116].
91 Deutsch A. Arthroscopic repair of partial-thickness tears of the rotator cuff. J Shoulder Elbow Surg. 2007;16(2):193-201. [pmid: 17113319].
92 Deutsch A, Kroll DG, Hasapes J, et al. Repair integrity and clinical outcome after arthroscopic rotator cuff repair using single-row anchor fixation: A prospective study of single-tendon and two-tendon tears. Journal of Shoulder and Elbow Surgery. 2008:845-852.
93 Ellman H, Kay SP, Wirth M. Arthroscopic treatment of full-thickness rotator cuff tears: 2- to 7-year follow-up study. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 1993;9(2):195-200.
94 Favard L, Berhouet J, Colmar M, et al. Massive rotator cuff tears in patients younger than 65 years. What treatment options are available?. Orthop Traumatol Surg Res. 2009;95(4 Suppl):19-26.
95 Fenlin JM Jr, Chase JM, Rushton SA, et al. Tuberoplasty: creation of an acromiohumeral articulation-a treatment option for massive, irreparable rotator cuff tears. J Shoulder Elbow Surg. 2002;11(2):136-142. [pmid: 11988724].
96 Franceschi F, Longo UG, Ruzzini L, et al. No advantages in repairing a type II superior labrum anterior and posterior (SLAP) lesion when associated with rotator cuff repair in patients over age 50: a randomized controlled trial. Am J Sports Med. 2008;36(2):247-253. [pmid: 17940144].
97 Franceschi F, Longo UG, Ruzzini L, et al. To detach the long head of the biceps tendon after tenodesis or not: outcome analysis at the 4-year follow-up of two different techniques. Int Orthop. 2007;31(4):537-545. [pmid: 16947053].
98 Franceschi F, Ruzzini L, Longo UG, et al. Equivalent clinical results of arthroscopic single-row and double-row suture anchor repair for rotator cuff tears: a randomized controlled trial. Am J Sports Med. 2007;35(8):1254-1260. [pmid: 17554104].
99 Fuchs B, Gilbart MK, Hodler J, et al. Clinical and structural results of open repair of an isolated one-tendon tear of the rotator cuff. J Bone Joint Surg Am. 2006;88(2):309-316. [pmid: 16452742].
100 Gartsman GM, Brinker MR, Khan M. Early effectiveness of arthroscopic repair for full-thickness tears of the rotator cuff: an outcome analysis. J Bone Joint Surg Am. 1998;80(1):33-40. [pmid: 9469306].
101 Gartsman GM. Massive, irreparable tears of the rotator cuff. Results of operative debridement and subacromial decompression. J Bone Joint Surg Am. 1997;79(5):715-721. [pmid: 9160944].
102 Gartsman GM, O‘Connor DP. Arthroscopic rotator cuff repair with and without arthroscopic subacromial decompression: a prospective, randomized study of one-year outcomes. J Shoulder Elbow Surg. 2004;13(4):424-426. [pmid: 15220883].
103 Gazielly DF, Gleyze P, Montagnon C. Functional and anatomical results after rotator cuff repair. Clinical Orthopaedics and Related Research. 1994:43-53.
104 Gladstone JN, Bishop JY, Lo IK, et al. Fatty infiltration and atrophy of the rotator cuff do not improve after rotator cuff repair and correlate with poor functional outcome. Am J Sports Med. 2007;35(5):719-728. [pmid: 17337727].
105 Grasso A, Milano G, Salvatore M, et al. Single-row vs. double-row arthroscopic rotator cuff repair: a prospective randomized clinical study. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2009;25(1):4-12.
106 Hata Y, Saitoh S, Murakami N, et al. Atrophy of the deltoid muscle following rotator cuff surgery. J Bone Joint Surg Am. 2004;86-A(7):1414-1419. [pmid: 15252087].
107 Henn RF III, Kang L, Tashjian RZ, et al. Patients with workers‘ compensation claims have worse outcomes after rotator cuff repair. J Bone Joint Surg Am. 2008;90(10):2105-2113. [pmid: 18829907].
108 Hsu SL, Ko JY, Chen SH, et al. Surgical results in rotator cuff tears with shoulder stiffness. Journal of the Formosan Medical Association. 2007;106(6):452-461. [pmid: 17588838].
109 Iannotti JP, Codsi MJ, Kwon YW, et al. Porcine small intestine submucosa augmentation of surgical repair of chronic two-tendon rotator cuff tears. A randomized, controlled trial. J Bone Joint Surg Am. 2006;88(6):1238-1244. [pmid: 16757756].
110 Ide J, Tokiyoshi A, Hirose J, et al. Arthroscopic repair of traumatic combined rotator cuff tears involving the subscapularis tendon. J Bone Joint Surg Am. 2007;89(11):2378-2388. [pmid: 17974879].
111 Ide J, Maeda S, Takagi K. Arthroscopic transtendon repair of partial-thickness articular-side tears of the rotator cuff: anatomical and clinical study. Am J Sports Med. 2005;33(11):1672-1679. [pmid: 16093533].
112 Ide J, Maeda S, Takagi K. A comparison of arthroscopic and open rotator cuff repair. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2005;21(9):1090-1098.
113 Ito J, Morioka T. Surgical treatment for large and massive tears of the rotator cuff. Int Orthop. 2003;27(4):228-231. [pmid: 12827299].
114 Kim SH, Ha KI, Park JH, et al. Arthroscopic vs. mini-open salvage repair of the rotator cuff tear: outcome analysis at 2 to 6 years‘ follow-up. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2003;19(7):746-754.
115 Kirschenbaum D, Coyle J, Leddy JP, et al. Shoulder strength with rotator cuff tears: Pre- and postoperative analysis. Clinical orthopaedics and related research. 1993;(288):174-178.
116 Klepps S, Bishop J, Lin J, et al. Prospective evaluation of the effect of rotator cuff integrity on the outcome of open rotator cuff repairs. Am J Sports Med. 2004;32(7):1716-1722. [pmid: 15494338].
117 Ko S-H, Friedman D, Seo D-K, et al. A Prospective Therapeutic Comparison of Simple Suture Repairs to Massive Cuff Stitch Repairs for Treatment of Small- and Medium-Sized Rotator Cuff Tears. Arthroscopy—Journal of Arthroscopic and Related Surgery. 2009;25(6):583-589.
118 Ko SH, Lee CC, Friedman D, et al. Arthroscopic single-row supraspinatus tendon repair with a modified mattress locking stitch: a prospective, randomized controlled comparison with a simple stitch. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2008;24(9):1005-1012.
119 Kose KC, Tezen E, Cebesoy O, et al. Mini-open vs. all-arthroscopic rotator cuff repair: Comparison of the operative costs and the clinical outcomes. Adv Ther. 2008;25(3):249-259. [pmid: 18363045].
120 Kreuz PC, Remiger A, Lahm A, et al. Comparison of total and partial traumatic tears of the subscapularis tendon. J Bone Joint Surg Br. 2005;87(3):348-351. [pmid: 15773644].
121 Lafosse L, Brozska R, Toussaint B, et al. The outcome and structural integrity of arthroscopic rotator cuff repair with use of the double-row suture anchor technique. J Bone Joint Surg Am. 2007;89(7):1533-1541. [pmid: 17606793].
122 Lafosse L, Jost B, Reiland Y, et al. Structural integrity and clinical outcomes after arthroscopic repair of isolated subscapularis tears. J Bone Joint Surg Am. 2007;89(6):1184-1193. [pmid: 17545420].
123 Levy O, Venkateswaran B, Even T, et al. Mid-term clinical and sonographic outcome of arthroscopic repair of the rotator cuff. J Bone Joint Surg Br. 2008;90(10):1341-1347. [pmid: 18827245].
124 Lichtenberg S, Liem D, Magosch P, et al. Influence of tendon healing after arthroscopic rotator cuff repair on clinical outcome using single-row Mason-Allen suture technique: a prospective, MRI controlled study. Knee Surg Sports Traumatol Arthrosc. 2006;14(11):1200-1206. [pmid: 16845547].
125 Liem D, Bartl C, Lichtenberg S, et al. Clinical outcome and tendon integrity of arthroscopic vs. mini-open supraspinatus tendon repair: a magnetic resonance imaging-controlled matched-pair analysis. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2007;23(5):514-521.
126 Lim JTK, Acornley A, Dodenhoff RM. Recovery after arthroscopic subacromial decompression: Prognostic value of the subacromial injection test. Arthroscopy-the Journal of Arthroscopic and Related Surgery. 2005;21(6):680-683.
127 Maier D, Jaeger M, Suedkamp NP, et al. Stabilization of the long head of the biceps tendon in the context of early repair of traumatic subscapularis tendon tears. J Bone Joint Surg Am. 2007;89(8):1763-1769. [pmid: 17671016].
128 Mallon WJ, Misamore G, Snead DS, et al. The impact of preoperative smoking habits on the results of rotator cuff repair. J Shoulder Elbow Surg. 2004;13(2):129-132. [pmid: 14997086].
129 Matis N, Hubner C, Aschauer E, et al. Arthroscopic transosseous reinsertion of the rotator cuff. Operative Orthopadie und Traumatologie. 2006;18(1):1-18. [pmid: 16534558].
130 McBirnie JM, Miniaci A, Miniaci SL. Arthroscopic repair of full-thickness rotator cuff tears using bioabsorbable tacks. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2005;21(12):1421-1427.
131 McCallister WV, Parsons IM, Titelman RM, et al. Open rotator cuff repair without acromioplasty. J Bone Joint Surg Am. 2005;87(6):1278-1283. [pmid: 15930537].
132 McIntyre LF, Norris M, Weber B. Comparison of Suture Welding and Hand-Tied Knots in Mini-Open Rotator Cuff Repair. Arthroscopy-Journal of Arthroscopic and Related Surgery. 2006;(8):836.
133 Milano G, Grasso A, Salvatore M, et al. Arthroscopic rotator cuff repair with and without subacromial decompression: a prospective randomized study. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2007;23(1):81-88.
134 Millar NL, Wu X, Tantau R, et al. Open vs. two forms of arthroscopic rotator cuff repair. Clin Orthop Related Res. 2009;467(4):966-978.
135 Misamore GW, Ziegler DW, Rushton JL. Repair of the rotator cuff. A comparison of results in two populations of patients. J Bone Joint Surg Am. 1995;77(9):1335-1339. [pmid: 7673282].
136 Mohtadi NG, Hollinshead RM, Sasyniuk TM, et al. A randomized clinical trial comparing open to arthroscopic acromioplasty with mini-open rotator cuff repair for full-thickness rotator cuff tears: disease-specific quality of life outcome at an average 2-year follow-up. Am J Sports Med. 2008;36(6):1043-1051. [pmid: 18354140].
137 Montgomery TJ, Yerger B. Management of rotator cuff tears: A comparison of arthroscopic debridement and surgical repair. Journal of Shoulder and Elbow Surgery. 1994;3(2):70-78.
138 Moser M, Jablonski MV, Horodyski M, et al. Functional outcome of surgically treated massive rotator cuff tears: a comparison of complete repair, partial repair, and debridement. Orthopedics. 2007;30(6):479-482. [pmid: 17598493].
139 Motycka T, Lehner A, Landsiedl F. Comparison of debridement vs. suture in large rotator cuff tears: long-term study of 64 shoulders. Arch Orthop Trauma Surg. 2004;124(10):654-658. [pmid: 15372278].
140 Mullett H, Venkat V, Massoud S, et al. Small & Medium Rotator Cuff Tears: Comparison of Arthroscopic Rotator Cuff Repair vs Arthroscopic Subacromial Decompression. 20th Congress of the European Society for Surgery of the Shoulder and the Elbow (SECEC-ESSSE 2006). Athens, Se. 2006:20-23.
141 Nam SC, Yong GR. Functional outcome of arthroscopic repair with concomitant manipulation in rotator cuff tears with stiff shoulder. Am J Sports Med. 2008;36(7):1323-1329. [pmid: 18539948].
142 Nho SJ, Brown BS, Lyman S, et al. Prospective analysis of arthroscopic rotator cuff repair: Prognostic factors affecting clinical and ultrasound outcome. Journal of Shoulder and Elbow Surgery. 2009:13-20.
143 Ogilvie-Harris DJ, Demaziere A. Arthroscopic debridement vs. open repair for rotator cuff tears. A prospective cohort study. J Bone Joint Surg Br. 1993;75(3):416-20. [pmid: 8496210].
144 Oh JH, Kim SH, Lee HK, et al. Moderate preoperative shoulder stiffness does not alter the clinical outcome of rotator cuff repair with arthroscopic release and manipulation. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2008;24(9):983-991.
145 Pai VS, Lawson DA. Rotator cuff repair in a district hospital setting: outcomes and analysis of prognostic factors. J Shoulder Elbow Surg. 2001;10(3):236-241. [pmid: 11408904].
146 Park JY, Chung KT, Yoo MJ. A serial comparison of arthroscopic repairs for partial- and full-thickness rotator cuff tears. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2004;20(7):705-711.
147 Park JY, Lhee SH, Choi JH, et al. Comparison of the clinical outcomes of single- and double-row repairs in rotator cuff tears. Am J Sports Med. 2008;36(7):1310-1316. [pmid: 18413680].
148 Pearsall AW, Ibrahim KA, Madanagopal SG. The results of arthroscopic vs. mini-open repair for rotator cuff tears at mid-term follow-up. J Orthop Surg. 2007;2:24.
149 Pillay R. Arthroscopic subacromial decompression for chronic shoulder impingement. Journal of Orthopaedic Surgery. 1994:67-70.
150 Porcellini G, Paladini P, Campi F, et al. Shoulder instability and related rotator cuff tears: arthroscopic findings and treatment in patients aged 40 to 60 years. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2006;22(3):270-276.
151 Prasad N, Odumala A, Elias F, et al. Outcome of open rotator cuff repair. An analysis of risk factors. Acta Orthop Belg. 2005;71(6):662-666. [pmid: 16459854].
152 Randelli PS, Arrigoni P, Cabitza P, et al. Autologous platelet rich plasma for arthroscopic rotator cuff repair. A pilot study. Disability and Rehabilitation. 2008:20-22. 1584. 1589.
153 Rokito AS, Cuomo F, Gallagher MA, et al. Long-term functional outcome of repair of large and massive chronic tears of the rotator cuff. J Bone Joint Surg Am. 1999;81(7):991-997. [pmid: 10428131].
154 Sauerbrey AM, Getz CL, Piancastelli M, et al. Arthroscopic vs. mini-open rotator cuff repair: a comparison of clinical outcome. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2005;21(12):1415-1420.
155 Scheibel M, Brown A, Woertler K, et al. Preliminary results after rotator cuff reconstruction augmented with an autologous periosteal flap. Knee Surg Sports Traumatol Arthrosc. 2007;15(3):305-314. [pmid: 16927071].
156 Scheibel M, Lichtenberg S, Habermeyer P. Reversed arthroscopic subacromial decompression for massive rotator cuff tears. J Shoulder Elbow Surg. 2004;13(3):272-278. [pmid: 15111896].
157 Severud EL, Ruotolo C, Abbott DD, et al. All-arthroscopic vs. mini-open rotator cuff repair: A long-term retrospective outcome comparison. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2003;19(3):234-238.
158 Sugaya H, Maeda K, Matsuki K, et al. Repair integrity and functional outcome after arthroscopic double-row rotator cuff repair. A prospective outcome study. J Bone Joint Surg Am. 2007;89(5):953-960. [pmid: 17473131].
159 Sugaya H, Maeda K, Matsuki K, et al. Functional and structural outcome after arthroscopic full-thickness rotator cuff repair: single-row vs. dual-row fixation. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2005;21(11):1307-1316.
160 Tashjian RZ, Henn RF, Kang L, et al. Effect of medical comorbidity on self-assessed pain, function, and general health status after rotator cuff repair. J Bone Joint Surg Am. 2006;88(3):536-540. [pmid: 16510819].
161 Tauro JC. Arthroscopic repair of large rotator cuff tears using the interval slide technique. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2004;20(1):13-21.
162 Tauro JC. Stiffness and rotator cuff tears: incidence, arthroscopic findings, and treatment results. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2006;22(6):581-586.
163 Torrens C, Lopez JM, Verdier E, et al. Open anterior acromioplasty with preservation of the coracoacromial ligament: A modified surgical technique. J Shoulder Elbow Surg. 2003;12(1):9-14. [pmid: 12610479].
164 Trenerry K, Walton JR, Murrell GA. Prevention of shoulder stiffness after rotator cuff repair. Clin Orthop Related Res. 2005:94-99.
165 Vad VB, Warren RF, Altchek DW, et al. Negative prognostic factors in managing massive rotator cuff tears. Clin J Sport Med. 2002;12(3):151-157. [pmid: 12011722].
166 Vaz SP. Bursectomy and acromial resection in arthroscopic treatment of sub-acromial impingement. Orthopedie traumatologie. 2000;10(1):13-19.
167 Verma NN, Dunn W, Adler RS, et al. All-arthroscopic vs. mini-open rotator cuff repair: a retrospective review with minimum 2-year follow-up. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2006;22(6):587-594.
168 Vitale MA, Vitale MG, Zivin JG, et al. Rotator cuff repair: an analysis of utility scores and cost-effectiveness. J Shoulder Elbow Surg. 2007;16(2):181-187. [pmid: 17399623].
169 Waibl B, Buess E. Partial-thickness articular surface supraspinatus tears: a new transtendon suture technique. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2005;21(3):376-381.
170 Walton JR, Bowman NK, Khatib Y, et al. Restore orthobiologic implant: not recommended for augmentation of rotator cuff repairs. J Bone Joint Surg Am. 2007;89(4):786-791. [pmid: 17403801].
171 Warner JJ, Tetreault P, Lehtinen J, et al. Arthroscopic vs. mini-open rotator cuff repair: a cohort comparison study. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2005;21(3):328-332.
172 Wilson F, Hinov V, Adams G. Arthroscopic repair of full-thickness tears of the rotator cuff: 2- to 14-year follow-up. Arthroscopy: The Journal of Arthroscopy & Related Surgery. 2002;18(2):136-144.
173 Youm T, Murray DH, Kubiak EN, et al. Arthroscopic vs. mini-open rotator cuff repair: a comparison of clinical outcomes and patient satisfaction. J Shoulder Elbow Surg. 2005;14(5):455-459. [pmid: 16194734].
174 Zumstein MA, Jost B, Hempel J, et al. The clinical and structural long-term results of open repair of massive tears of the rotator cuff. J Bone Joint Surg Am. 2008;90(11):2423-2431. [pmid: 18978411].
175 Boissonnault WG, Badke MB, Wooden MJ, et al. Patient outcome following rehabilitation for rotator cuff repair surgery: the impact of selected medical comorbidities. J Orthop Sports Phys Ther. 2007;37(6):312-319. [pmid: 17612357].
176 Brady B, Redfern J, MacDougal G, et al. The addition of aquatic therapy to rehabilitation following surgical rotator cuff repair: a feasibility study. Physiother Res Int. 2008;13(3):153-161. [pmid: 18548557].
177 Delbrouck C, Dauty M, Huguet D, et al. Rehabilitation after shoulder rotator cuff surgery: in-patient or day-hospitalization (about 76 cases). [French]. Ann Readapt Med Phys. 2003;46(4):207-213. [pmid: 12787979].
178 Hayes K, Ginn KA, Walton JR, et al. A randomised clinical trial evaluating the efficacy of physiotherapy after rotator cuff repair. Australian Journal of Physiotherapy. 2004;50(2):77-83. [pmid: 15151491].
179 Klintberg Hultenheim I, Gunnarsson A-C, Svantesson U, et al. Early loading in physiotherapy treatment after full-thickness rotator cuff repair: A prospective randomized pilot-study with a two-year follow-up. Clin Rehabil. 2009;23(7):622-638. [pmid: 19482895].
180 LaStayo PC, Wright T, Jaffe R, et al. Continuous passive motion after repair of the rotator cuff. A prospective outcome study. J Bone Joint Surg Am. 1998;80(7):1002-1011. [pmid: 9698005].
181 Marc T, Gaudin T, Teissier J. Rehabilitation after rotator cuff repairs: factors influencing functional outcome at two years [French]. Kinesitherapie Revue. 2009:36-44.
182 Michael JWP, Konig DP, Imhoff AB, et al. Efficiency of a postoperative treatment after rotator cuff repair with a continuous passive motion device (CPM). [German]. Z Orthop Ihre. 2005;143(4):438-445.
183 Milroy DR, Marland JD, Parent EC, et al. Rotator cuff repair: the effect of a standardized post-operative physical therapy protocol vs. a non-standardized postoperative protocol. Nashville, Tennessee, February 6–9, 2008. J Orthop Sports Phys Ther. 2008;38(1):A17-A18.
184 Raab MG, Rzeszutko D, O‘Connor W, et al. Early results of continuous passive motion after rotator cuff repair: a prospective, randomized, blinded, controlled study. Am J Orthop. 1996;25(3):214-220. [pmid: 8775698].
185 Roddey TS, Olson SL, Gartsman GM, et al. A randomized controlled trial comparing 2 instructional approaches to home exercise instruction following arthroscopic full-thickness rotator cuff repair surgery. J Orthop Sports Phys Ther. 2002;32(11):548-559. [pmid: 12449254].
186 Ghroubi S, Chaari M, Elleuch H, et al. Functional and quality of life outcome of none operated rotator cuff tears. [French]. Annales de Readaptation et de Medecine Physique. 2008;(9):714-721.
187 Hawkins RH, Dunlop R. Nonoperative treatment of rotator cuff tears. Clin Orthop Related Res. 1995:178-188.
188 Heers G, Anders S, Werther M, et al. Efficacy of home exercises for symptomatic rotator cuff tears in correlation to the size of the defect. [German]. Sportverletz Sportschaden. 2005;19(1):22-27. [pmid: 15776325].
189 Kane TP, Rogers P, Hazelgrove J, et al. Pulsed radiofrequency applied to the suprascapular nerve in painful cuff tear arthropathy. J Shoulder Elbow Surg. 2008;17(3):436-440. [pmid: 18328740].
190 Koubaa S, Ben Salah FZ, Lebib S, et al. Conservative management of full-thickness rotator cuff tears. A prospective study of 24 patients. [French]. Ann Readapt Med Phys. 2006;49(2):62-67. [pmid: 16387384].
191 Leroux JL, Thomas E, Azema MJ, et al. Functional pattern of 115 rotator cuff tears. Eur J Phys Med Rehabil. 1993;3(6):242-247.
192 Levy O, Mullett H, Roberts S, et al. The role of anterior deltoid reeducation in patients with massive irreparable degenerative rotator cuff tears. Journal of Shoulder and Elbow Surgery. 2008:863-870.
193 Scheuermann R, Behrens P, Egbers HJ, et al. The early functional physiotherapy of the shoulder backed up by an active shoulder support. [German]. Aktuelle Traumatologie. 1991:58-63.
194 Shibata Y, Midorikawa K, Emoto G, et al. Clinical evaluation of sodium hyaluronate for the treatment of patients with rotator cuff tear. J Shoulder Elbow Surg. 2001;10(3):209-216. [pmid: 11408900].
195 De Carli A, Vulpiani M, Russo A, et al. Reparable Rotator Cuff Tears: Surgery vs Shock Wave Therapy. 20th Congress of the European Society for Surgery of the Shoulder and the Elbow (SECEC-ESSSE 2006). Athens, Se. 2006:20-23.
196 Lunn JV, Castellanos-Rosas J, Tavernier T, et al. A novel lesion of the infraspinatus characterized by musculotendinous disruption, edema, and late fatty infiltration. J Shoulder Elbow Surg. 2008;17(4):546-553. [pmid: 18372195].
197 Yamada N, Hamada K, Nakajima T, et al. Comparison of conservative and operative treatments of massive rotator cuff tears. Tokai Journal of Experimental & Clinical Medicine. 2000;25(4–6):151-163. [pmid: 11358030].
198 Moher D, Schulz KF, Altman DG, et al. The CONSORT statement: Revised recommendations for improving the quality of reports of parallel group randomized trials. Ann Intern Med. 2001;134(8):657-662. [pmid: 11304106].
199 von Elm E, Altman DG, Egger M, et al. The Strengthening of Reporting of Observational Studies in Epidemiology (STROBE) statement: guidelines for reporting observational studies. J Clin Epidemiol. 2008;61(4):344-349. [pmid: 18313558].