# Discussion

## Summary of Findings

This report provides a comprehensive synthesis of the evidence on the comparative effectiveness of nonoperative and operative interventions for RC tears. The findings and strength of evidence for comparative studies are summarized in Table 66. The variability in the studies in the table illustrates the numerous comparisons that have been made across the studies in this area. Uncontrolled studies were not included in the table, as they represent an extremely low grade on the hierarchy of evidence. The result is that there is sparse data available for most interventions. This precludes firm conclusions for any single approach or for the optimal overall management of this condition. The majority of the data is derived from studies of low methodological quality or lower in the hierarchies of evidence. Sample sizes were generally moderate and varied considerably from study to study, with an overall median of 53 patients per study (IQR 30 to 85). Overall, the evidence shows that all interventions result in substantial improvements; however, few differences of clinical importance are evident when comparisons between interventions are available. The following is a summary of the evidence for the different types of interventions.

Table 66 Summary of strength of evidence for nonoperative and operative interventions

Comparison (number of studies) | Strength of evidence | Summary
Early vs. late repair
Early RCR vs. late RCR (n=1) | Low | The evidence was too limited to make a conclusion.
Operative approaches
Open RCR vs. mini-open RCR (n=3) | Moderate | No statistically significant or clinically important difference for function. Some evidence for earlier return to work or sports (by approximately 1 month) with mini-open repairs.
Open RCR vs. mini-open RCR (n=3) | Low | The evidence was too limited to make a conclusion for health-related quality of life.
Mini-open RCR vs. arthroscopic RCR (n=10) | Moderate | No difference in function or cuff integrity.
Open RCR vs. arthroscopic RCR (n=3) | Low | The evidence was too limited to make a conclusion.
Open or mini-open RCR vs. arthroscopic RCR (n=2) | Moderate | No difference in function.
Open or mini-open RCR vs. arthroscopic RCR (n=2) | Low | The evidence was too limited to make a conclusion for cuff integrity.
Open RCR vs. open or arthroscopic debridement (n=4) | Moderate | Some evidence for greater improvement in function for open RCR.
Arthroscopic RCR with acromioplasty vs. without acromioplasty (n=3) | Moderate | No difference in function.
Arthroscopic RCR vs. acromioplasty alone | Low | The evidence was too limited to make a conclusion.
Biceps tenotomy vs. tenodesis (n=1) | Low | The evidence was too limited to make a conclusion.
RCR vs. palliative treatment (n=1) | Low | The evidence was too limited to make a conclusion.
Arthroscopic RCR with SLAP repair vs. arthroscopic RCR with biceps tenotomy (n=1) | Low | The evidence was too limited to make a conclusion.
Mini-open RCR plus tenodesis with detachment vs. without detachment (n=1) | Low | The evidence was too limited to make a conclusion.
Arthroscopic debridement with biceps tenotomy vs. without tenotomy (n=1) | Low | The evidence was too limited to make a conclusion.
Complete open RCR vs. partial open RCR vs. debridement (n=1) | Low | The evidence was too limited to make a conclusion.
Open RCR with classic open acromioplasty vs. open RCR with modified open acromioplasty (n=1) | Low | The evidence was too limited to make a conclusion.
Operative techniques
Single-row vs. double-row suture anchor fixation (n=6) | Moderate | No clinically important difference for function and no difference for cuff integrity.
Bioabsorbable tacs vs. suture tying (n=1) | Low | The evidence was too limited to make a conclusion.
Side-to-side vs. tendon-to-bone fixation (n=1) | Low | The evidence was too limited to make a conclusion.
Nonabsorbable vs. absorbable sutures (n=1) | Low | The evidence was too limited to make a conclusion.
Bioabsorbable corkscrews vs. metal suture anchor (n=1) | Low | The evidence was too limited to make a conclusion.
Mattress locking vs. simple stitch (n=2) | Moderate | No difference in cuff integrity.
Mattress locking vs. simple stitch (n=2) | Low | The evidence was too limited to make a conclusion for function.
Mattress vs. transosseous suture (n=1) | Low | The evidence was too limited to make a conclusion.
Ultrasonic welding vs. hand-tied knots (n=1) | Low | The evidence was too limited to make a conclusion.
Staple fixation vs. side-to-side suture (n=1) | Low | The evidence was too limited to make a conclusion.
Operative augmentation
Porcine small intestine submucosa vs. no augmentation (n=2) | Low | The evidence was too limited to make a conclusion.
Patch graft vs. no augmentation (n=1) | Low | The evidence was too limited to make a conclusion.
Postoperative rehabilitation
Continuous passive motion with PT treatment vs. PT treatment (n=3) | Moderate | No clinical or statistical difference in function. Some evidence for earlier return to work with continuous passive motion.
Aquatic therapy with land-based therapy vs. land-based therapy (n=1) | Low | The evidence was too limited to make a conclusion.
Inpatient vs. day patient rehabilitation (n=1) | Low | The evidence was too limited to make a conclusion.
Individualized PT program with home exercise vs. home exercise (n=1) | Low | The evidence was too limited to make a conclusion.
Progressive vs. traditional loading (n=1) | Low | The evidence was too limited to make a conclusion.
Inpatient rehabilitation vs. outpatient CGE (n=1) | Low | The evidence was too limited to make a conclusion.
Standardized vs. non-standardized PT program (n=1) | Low | The evidence was too limited to make a conclusion.
Videotape vs. PT home exercise instruction (n=1) | Low | The evidence was too limited to make a conclusion.
Nonoperative interventions
Sodium hyaluraonate vs. dexamethasone (n=1) | Low | The evidence was too limited to make a conclusion.
Rehabilitation vs. no rehabilitation (n=1) | Low | The evidence was too limited to make a conclusion.
Physical therapy, oral medications and steroid injection vs. physical therapy, oral medications and no steroid injection (n=1) | Low | The evidence was too limited to make a conclusion.
Nonoperative vs. operative treatment
Shock-wave therapy vs. mini-open RCR (n=1) | Low | The evidence was too limited to make a conclusion.
Steroid injection, physical therapy, and activity modification vs. open repair (n=1) | Low | The evidence was too limited to make a conclusion.
Physical therapy vs. open or mini-open RCR | Low | The evidence was too limited to make a conclusion.
Physical therapy treatment, oral medication, and steroid injection vs. arthroscopic debridement vs. open repair (n=1) | Low | The evidence was too limited to make a conclusion.
Passive stretching, strengthening, and corticosteroid injection vs. open repair with acromioplasty (n=1) | Low | The evidence was too limited to make a conclusion.

CGE = Concept Global d’Epaule; PT = physical therapy; RCR = rotator cuff repair; SLAP = superior labral from anterior to posterior

KQ1: Early vs. late repair. Only one study comparing early surgical repair vs. late surgical repair after failed nonoperative treatment was identified. There was low evidence in favor of early repair for function and no difference between groups for cuff integrity. The paucity of evidence related to this question is of particular concern, as primary care providers are frequently faced with the dilemma of whether to refer patients to surgery immediately or delay surgery by opting for initial nonoperative treatment.

KQ2a: Comparative effectiveness of operative approaches. The most frequent comparison was mini-open vs. arthroscopic rotator cuff repair; this comparison provided moderate evidence for no difference in function or cuff integrity between the two approaches. There was also moderate evidence showing no statistical or clinically important differences in function between open and mini-open repairs; however, there was some evidence suggesting an earlier return to work by approximately 1 month for mini-open repairs. There was moderate evidence for no difference in function between open or mini-open vs. arthroscopic repairs and arthroscopic repairs with and without acromioplasty. There was moderate evidence for greater improvement in function for open repairs compared to debridement only. The strength of evidence was low for the remaining comparisons and outcomes; hence, the evidence was too limited to make a conclusion.

KQ2b: Comparative effectiveness of operative techniques. The most frequent comparison was single-row vs. double-row fixation. There was moderate evidence in favour of double-row fixation for function, yet the clinical significance of the difference is questionable, and no difference for cuff integrity. Moderate evidence showed no difference between mattress stitch and simple stitch for cuff integrity. The evidence was too limited to make conclusions for the other techniques studied.

KQ2c: Comparative effectiveness of operative augmentation. Three relatively small studies evaluated two different augmentation techniques, and no overall conclusions were possible.

KQ2d: Comparative effectiveness of postoperative rehabilitation. The most frequent comparison was continuous passive motion with physical therapy vs. physical therapy alone. This resulted in moderate evidence showing no clinical or statistical difference in function but low evidence for earlier return to work with continuous passive motion. The evidence for other aspects of postoperative rehabilitation was too limited to make conclusions.

KQ3: Comparative effectiveness of nonoperative interventions. Three studies compared different nonoperative interventions; hence, no overall conclusions were possible regarding any single approach.

KQ4: Comparative effectiveness of nonoperative vs. operative treatment. Five studies compared different nonoperative and operative interventions. Because the interventions and comparisons differed across the studies, the evidence was too limited to make conclusions regarding the relative effectiveness of the individual modalities.

KQ5: Complications. A total of 34 different complications were reported in 85 studies. The incidence of complications was generally low, yet studies varied considerably in their risk estimates. In 21 studies, it was reported that no complication occurred during the course of the study. Generally, the benefit of receiving treatment for RC tears appears to outweigh the risk of associated harms.

KQ6: Prognostic factors. The variety of prognostic factors examined across many different outcomes and the inconsistency among authors’ conclusions make it difficult to identify predictors of good outcome for nonoperative and operative treatments. However, older age, increasing tear size and extent of preoperative symptoms were repeatedly found to be associated with recurrent tears. Sex, WCB status, and duration of symptoms were not found to be associated with poorer outcomes in the majority of studies that examined these variables.

## Applicability

The study populations in this body of evidence were relatively homogeneous. The vast majority included only patients with full-thickness tears. There was more variation in the number of tendons involved with many studies including patients with only one torn tendon (e.g., supraspinatus) while others included any tendon and tendon combination (e.g., supraspinatus plus infraspinatus, supraspinatis plus infraspinatus plus subscupularis). Studies similarly differed in the number and types of comorbidities permitted for enrollement of study patients. The mean age was clustered between 50 and 65 years, with males comprising an average slightly more than half of the study participants. The duration since symptom onset was not reported in the majority of studies, but when reported was generally between 12 and 18 months.

The other issue regarding applicability for this body of evidence relates to the practitioners administering the interventions (e.g., surgeons, physical therapists, or other healthcare providers). Outcome effects may differ between the trials and real life practice based on practitioners’ skills and experience, volume of surgery, and variations or rigor surrounding cointerventions or procedural protocols.

## Limitations of the Existing Evidence

The strength of evidence was low for the majority of interventions that were evaluated and compared in the management of RC tears. The low grade was driven by the high risk of bias within individual studies and the lack of consistency and precision across studies. The majority of studies in this field are lower in the hierarchies of evidence, with most studies lacking an independent comparison or control group.

Overall, there were 21 RCTs and 6 CCTs; however, all of these were assessed as high risk of bias based on an empirically derived tool for assessing risk of bias developed by The Cochrane Collaboration. The trial features that were most problematic were inadequate blinding, inadequate allocation concealment, and incomplete outcome data. Inadequate blinding is an important limitation in this body of research due to the nature of the intervention and can lead to exaggerated effect estimates. Methodological approaches to adequately prevent knowledge of the intervention should be employed, such as blinding outcome assessors to treatment status. While blinding is not always feasible, adequate allocation concealment is always possible in an RCT and should be routinely employed. Incomplete outcome data or missing data was a problem in a number of trials due to loss to followup and inadequate handling of missing data in the reporting and/or analysis. Loss to followup was more problematic in studies that extended over a longer period of time. While attrition might be expected when the followup is over a number of years, it can exaggerate treatment effects and the potential for this bias should be considered when designing, conducting, and interpreting research.

One of the values of randomization is that all potential confounders, both known and unknown, are accounted for; hence, the results observed can be more closely attributed to the treatment under study. The majority of studies that were included in this report were not randomized; therefore, they are particularly vulnerable to bias resulting from lack of comparability between the groups under study. Moreover, the majority of studies did not control for important potential confounders in their design or analysis.

The strength of evidence was also rated low due to the lack of consistency and precision of results across studies. This is primarily due to the varied comparisons made across this body of literature with relatively few studies comparing the same interventions. Lack of consistency across studies may also be attributable to the variation in pathological presentation of rotator cuff disease. While the majority of patients had full-thickness tears, the size and configuration of the tears, degree of fatty infiltration, and number and type of comorbidities varied widely across the studies included in the review. Also contributing to the lack of consistency and precision was the variability in outcomes assessed across the studies.

The choice of outcomes and measurement tools needs attention in this area of research. The most common outcome assessed was function; however, 21 different tools were used for this purpose and often multiple tools were used within the same study. This makes comparisons across studies challenging. Moreover, it is unclear whether these functional scores are measuring the same construct to allow comparisons across studies that use different tools. There was also inconsistency in which ranges of motion were assessed in the studies and the vast majority of studies failed to report whether measurements were obtained actively or passively. Contributing to the inconsistency was the varied time points at which outcomes were assessed.

There was a paucity of evidence for some key questions that were considered clinically important. In particular, there was only one study that addressed whether early vs. late surgical repair results in better patient outcomes (Question 1). This question was identified as a critical issue by our technical expert panel, as there is uncertainty regarding whether, for what duration, and for which patients nonoperative treatment should be attempted prior to surgery. In addition, only three studies were identified that compared the effectiveness of nonoperative with operative treatment. Thus, firm conclusions on the optimal management of RC tears could not be made.

The body of evidence was insufficient for many outcomes that were considered by our review team to be clinically important a priori. These included health-related quality of life, function, return to work, and tendon healing. Consensus on clinically and patient-important outcomes is needed. Many studies only reported results for one or two outcomes which may suggest selective outcome reporting or may simply reflect the retrospective nature of the studies.

Discussion and consensus is required regarding what differences are clinically important when comparing interventions. In some meta-analyses, a statistically significant difference was observed but the difference on the measurement scale was not deemed to be clinically important (e.g., less than 10 points on a 100-point scale). Such information is critical for designing future research (e.g., planning for adequate sample sizes) and interpreting the findings.

A further limitation of this body of evidence was the limited or inconsistent reporting with respect to a number of variables and design considerations. For instance, some of the interventions were inadequately described to allow for replication in practice or determining applicability. This was more problematic for the nonoperative interventions. Specifically, studies often reported using physical therapy as an intervention, without further description of treatment components or delivery. Sufficient detail should be reported regarding the specific components of the interventions; timing, and frequency of each component; training and experience of the individuals implementing the interventions; and, cointerventions. As another example, lack of comprehensive assessment and reporting across studies for complications resulted in challenges for interpreting these data. For instance, some studies reported no complications while others did not comment on complications. It is not known whether these investigators looked for complications systematically or which complications they looked for. Further, definitions of the same complications and assessment of complications (e.g., clinical vs. imaging) may have varied across studies.

## Future Research

The following general recommendations for future research are based on the preceding discussion regarding the limitations of the current evidence base:

- All future studies should employ a comparison or control group and ensure comparability of treatment groups, optimally through the use of randomization.
- Future research should seek to minimize bias by blinding outcome assessors, using validated and standardized outcome assessment instruments, adequately concealing allocation (where applicable), and handling and reporting missing data appropriately.
- Studies examining the long-term effectiveness of treatments over the course of several years are needed; at the very least, studies should follow patients for a minimum of 12 months.
- Interventions and comparisons chosen for study should be guided by consensus regarding the most promising and/or controversial interventions in order to avoid numerous studies on disparate interventions.
- Consensus on clinically and patient-important outcomes is needed to ensure consistency and comparability across future studies. Moreover, consensus on minimal clinically important differences is needed to guide study design and interpretation of results.
- Future research needs to be reported in a consistent and comprehensive manner to allow for appropriate interpretation of results.

This review identified numerous comparators for which the evidence base is sparse and which are priorities for future research. There is a need for primary research comparing the effectiveness of early vs. delayed surgery, as much uncertainly remains regarding the appropriate timing of treatment. Currently, patients generally undergo surgery after several months of failed conservative treatment, however evidence is needed to determine whether, for how long, and for which types of patients surgery should be delayed. Further, evidence comparing the relative effectiveness of operative vs. nonoperative treatments, and among the various nonoperative treatment options, was extremely sparse. Future research examining these comparisons should ensure that the diagnosis of rotator cuff tears is confirmed using imaging and that the interventions are described in sufficient detail to allow for adequate assessment and replication of treatments. Although the majority of studies identified in this review focused on the comparative effectiveness of operative treatments, there was sparse evidence for most individual treatment comparisons, leaving many unanswered questions. Investigators should use a streamlined approach in evaluating operative treatments, beginning with broad treatment questions prior to focusing on detailed procedures. One main unanswered question is the relative effectiveness among the approaches to repair (open, mini-open or arthroscopic). There is currently much enthusiasm for the use of arthroscopic procedures, however evidence of superior outcomes compared to open repair should be established prior to investing resources into this costly and technically difficult procedure.

Investigators should select the highest level of evidence appropriate of their research questions when designing future studies. Authors may find tools such as the CONSORT198 and the STROBE199 statements helpful in designing and reporting on randomized controlled trials and cohort studies, respectively. In addition, the trial comparing early vs. delayed repair by Moosmayer et al.66 provides a good example of a well-designed and conducted study in this field.

## Conclusions

Numerous interventions and comparisons have been studied for the nonoperative and operative management of RC tears. The data are sparse for most interventions which prevents making firm conclusions for any single approach or for the optimal overall management of this condition. Overall, the evidence shows that all interventions result in substantial improvements; however, few differences of clinical importance are evident when comparisons between interventions are available. The majority of the data were derived from studies of low methodological quality or lower in the hierarchies of evidence.

In terms of operative approaches, there is moderate evidence demonstrating no difference in function between mini-open and arthroscopic repairs, open and mini-open repairs, open or mini-open and arthroscopic repairs, and arthroscopic repairs with and without acromioplasty. There is some evidence suggesting an earlier return to work for mini-open as compared with open repairs and greater improvement in function for open repairs compared with arthroscopic debridement. For operative techniques, there is moderate evidence for no clinically important difference in function or cuff integrity between single-row and double-row fixation, and no difference for cuff integrity between mattress locking and simple stitch. The evidence was too limited to make conclusions regarding comparative effectiveness for the other surgical approaches and techniques studied. In terms of postoperative rehabilitation, there is moderate evidence demonstrating no difference in function but earlier return to work for continuous passive motion with physical therapy compared with physical therapy alone. No conclusions were possible for studies evaluating operative augmentation, nonoperative interventions, and those comparing nonoperative and operative treatments. In general the rates of complications were low across all interventions. There is some evidence that tear size and age may modify outcomes; while, WCB status, sex, and duration of symptoms generally showed no significant impact.

Future research should incorporate design elements to minimize bias in treatment effects including randomization where possible, blinding of outcome assessors, comparability of study groups, and appropriate handling and reporting of missing data. Consensus is needed on clinically and patient-important outcomes, as well as minimum clinically-important differences. Consistency across studies is needed in choice of outcomes and measurement tools. Comprehensive and consistent reporting in future studies will allow for more accurate comparisons and the interpretation of findings across studies as well as greater understanding with respect to the applicability of the findings.