# Results

## Literature Search

The search strategy identified 5,677 citations from electronic databases. After screening titles and abstracts, 1008 studies were assessed to be potentially relevant. Two additional study were identified for further examination by hand searching the reference lists from previous systematic reviews and conference proceedings. The full text articles of twenty-nine studies could not be retrieved through the university interlibrary loan service (Appendix F). Therefore, the full text of 981 potentially relevant reports was retrieved and evaluated for inclusion in the review. The application of the selection criteria to the 981 reports resulted in 137 studies being included and 844 being excluded (Figure 2).

Figure 2 Flow-diagram for study retrieval and selection

Flow-diagram for study retrieval and selection. The search strategy identified 5,677 citations from electronic databases. After screening titles and abstracts, 1008 studies were assessed to be potentially relevant. Two additional studies were identified for further examination by hand searching the reference lists from previous systematic reviews and conference proceedings. The full text articles of twenty-nine studies could not be retrieved through the university interlibrary loan service. Therefore, the full text of 981 potentially relevant reports was retrieved and evaluated for inclusion in the review. The application of the selection criteria to the 981 reports resulted in 137 studies being included and 844 being excluded. The five main reasons for excluding studies from this review were (1) ineligible study design (n=182), (2) the article did not report on primary research (n=153), (3) the diagnosis of RC tear was not confirmed using imaging or intraoperative findings (n=107), (4) no baseline data was reported in a single-arm study (n=89), and (5) the study was not published in English (n=79). Two hundred and thirty-four studies were excluded for other reasons.

The five main reasons for excluding studies from this review were (1) ineligible study design (n=182), (2) the article did not report on primary research (n=153), (3) the diagnosis of RC tear was not confirmed using imaging or intraoperative findings (n=107), (4) no baseline data was reported in a single-arm study (n=89), and (5) the study was not published in English (n=79). Two hundred and thirty-four studies were excluded for other reasons (Figure 2). A complete list of excluded studies and reasons for exclusion is provided in Appendix F.

Thirteen studies were excluded because they were considered to be multiple publications; that is, they were either abstracts of full reports, reports published subsequent to the primary study or reported secondary outcomes. Generally, the report that provided the longest followup data or the largest sample size was regarded as the primary study. For one study, the initial publication was included since it reported full baseline data,60 however the 10-year followup data from a subsequent publication was incorporated into the results.61 In two instances, both the primary publication62,63 and their respective secondary publications64,65 were included in the review, since the articles focused on different key questions.

## Description of Included Studies

One hundred and thirty-seven studies provided evidence on the six key questions addressed in this report. Appendix F describes the key characteristics of the studies included in the review. One study66 examined the effect of early vs. late surgical RCR (Question 1). All of the included studies addressed the effectiveness of an intervention for the treatment of RC tears (Questions 2 to 4). Operative treatments (Question 2) were evaluated in 113 (82 percent) studies,60,62–65,67–174 while postoperative rehabilitation procedures (Question 2) were examined in 11 (8 percent) studies.175–185 Ten (7 percent) studies165,186–194 examined the effectiveness of nonoperative treatments (Question 3) and five (4 percent) studies66,165,195–197 compared nonoperative therapy to operative intervention (Question 4). One of the studies165 included four study arms (two operative and two nonoperative) and was included in three categories: operative interventions, nonoperative interventions and nonoperative vs. operative interventions. Complications (Question 5) were addressed in 85 studies.63–68,70,73–78,80–84,88,91–99,101,103,107–114,117–122,124,127,129–132,134,136–140,145–147,151–153,155–159,161–163,167,169–171,173,174,176,179,180,182,184,186,189,190,194 Prognostic factors (Question 6) were examined in 72 studies.60,62,64,65,68,70–77,80,83,84,86,89,90,92,93,99–101,103–105,107–110,112,114–117,119–125,128,130,131,133–135,141,142,144,145,147–149,151,154,157,160,162,164,166,173–175,180,181,184,187,188,197

The studies were published between 1990 and 2010 (median=2005 [interquartile range (IQR): 2003 to 2007]). All of the studies were published as peer reviewed articles, with the exception of four abstracts.87,140,183,195 Studies were conducted in the United States (n=49, 36 percent), Europe (n=56, 41 percent), Asia (n=18, 13 percent) and other regions (n=14, 10 percent). The studies were published in English, with the exception of four French (two nonoperative186,190 and two postoperative rehabilitation177,181) and three German (two nonoperative188,193 and one postoperative rehabilitation182) studies. The number of participants in the studies ranged from 12 to 224 (median=55 [IQR: 33 to 93]). The mean age of study participants ranged from 41.2 to 80 years.

Of the 137 included studies, 21 (15 percent) were RCTs. All were parallel, two-arm, superiority trials. One RCT194 examined nonoperative interventions, twelve71,73,78,81,96–98,102,105,109,133,136 evaluated operative interventions and six178–180,182,184,185 assessed postoperative rehabilitation and two studies66,195 compared operative and nonoperative treatments. Six (4 percent) of the included studies were CCTs, of which five assessed operative treatments114,117,137,143,163 and one176 assessed postoperative rehabilitation. Thirteen prospective cohort studies were included. Operative interventions were evaluated in eleven,64,72,77,85,88,112,118,129,140,147,148 while one study196 compared operative to nonoperative treatments, and one177 evaluated postoperative rehabilitation. There were 26 retrospective cohort studies included in the review, including two postoperative rehabilitation study,181,183 22 operative studies,63,68,75,87,94,106,113,119,125,132,134,138,139,154,157,159,165,167,170–173 one nonoperative study191 and two studies comparing nonoperative vs. operative treatments.165,197

There were 71 uncontrolled studies, including 55 BA studies, 10 prospective cohorts with BA data, and five retrospective cohort with BA data. Of the BA studies, six186,187,189,190,192,193 evaluated a nonoperative intervention, 48 examined an operative intervention,60,65,67,69,70,74,76,79,80,82–84,89–91,95,99–101,103,104,108,110,111,115,116,120–124,127,130,131,142,145,151–153,155,156,158,160,161,166,168,169,174 and one175 assessed postoperative rehabilitation. Nine of 10 prospective cohort studies with BA data evaluated operative interventions,62,86,92,93,107,126,141,144,146 while the remaining study188 examined a nonoperative intervention. All five retrospective cohorts with BA data examined operative interventions.128,135,149,150,162 One case-control BA study164 assessed an operative procedure.

## Methodological Quality of Included Studies

The methodological quality of each included study was assessed by two independent reviewers and the consensus ratings are presented in Appendix D, Tables D1 to D3. A summary of the overall quality trends by study design is presented below.

### Randomized Controlled and Controlled Clinical Trials

The risk of bias assessments for each of the RCTs and CCTs is presented in Appendix D, Table D1. All of the 21 RCTs were rated as having high risk of bias for both patient-rated and clinically assessed outcomes. The allocation sequence was adequately generated in 16 trials. 66,73,78,96–98,102,105,109,133,136,178–180,182,185 Allocation concealment was adequate in eight trials,66,78,96,98,105,133,136,179 inadequate in three trials,73,81,178 and unclear in the remaining trials. No trial used sufficient methods to ensure the blinding of participants and outcome assessors for either patient-reported or clinically assessed outcomes. Half of the RCTs adequately addressed incomplete outcome data (n=11).66,73,78,81,97,102,105,109,136,182,194 All but two studies136,195 were free of selective outcome reporting, and other sources of bias were identified in five trials.78,109,136,182,184 Five trials reported conducting an intention-to-treat analysis.66,96,98,136,182

The six CCTs were similarly all rated as having high risk of bias. None of these trials reported adequate sequence generation, allocation concealment or blinding. Three trials addressed incomplete outcome data adequately.114,117,163 All of the trials were free of suggestion of selective outcome reporting. The impact of other sources of bias was unclear in four studies.114,137,163,176 Intention-to-treat analysis was reported in one CCT.176

The source of funding was not reported in the majority of the trials (n=15, 56 percent). For studies that reported funding, sources included an academic institution,136,179 government,109,136,178 foundation136,185 and industry.78,109,182 Five studies reported receiving no funding.73,105,117,143,180

### Cohort Studies

The Newcastle-Ottawa quality assessment of the 39 cohort studies is presented in Appendix D, Table D2. Data was prospectively collected in 13 cohort studies64,72,77,85,88,112,118,129,140,147,148,177,196 and retrospective in 26 studies.63,68,75,87,94,106,113,119,125,132,134,138,139,154,157,159,165,167,170–173,181,183,191,197 Overall, the methodological quality of the cohort studies was moderate (median score=5/8 stars; IQR: 4 to 6). The majority enrolled patients that were rated to be truly or somewhat representative of average patients in the community (n=28, 72 percent). The nonexposed cohort was drawn from the same community as the exposed cohort in 36 studies; in three studies, the nonexposed cohort was drawn from a different source.94,139,197 All studies ascertained the exposure status from a secure source, most commonly from surgical records. Nearly half of the studies (n=18, 46 percent) controlled for potential confounding variables in their design or analysis.72,75,77,87,112,119,125,134,147,148,154,159,165,167,170,173,181,196 In four studies, there was independent blind outcome assessment;112,134,147,148 the remaining studies had self-reported outcomes (n=20, 51 percent), were described as unblinded (n=6, 15 percent), or did not describe methods for outcome assessment (n=9, 23 percent). All of the cohort studies had a followup duration of at least 12 months, with the exception of two postoperative rehabilitation studies177,183 and one nonoperative study.191 The rate of followup was considered unlikely to introduce bias in the majority of studies (n=24, 62 percent); however, nine studies were rated as having inadequate followup,72,113,119,129,132,134,157,167,177 and six did not describe the followup rate.85,87,94,106,138,140

Source of funding was not reported by 29 of the cohort studies (74 percent). One study received government funding,148 one received foundation and government funding,72 and one received industry funding.134 The remaining seven studies reported receiving no funding.68,75,94,106,125,147,170

### Uncontrolled Studies

The methodological quality of the 55 BA studies, 15 cohort studies with BA data, and one case-control study with BA data was assessed for three domains: consecutive enrollment, incomplete outcome data, and approach to outcome assessment. The quality assessment is presented in Appendix D, Table D3. Of the 71 studies, 45 (63 percent) reported consecutive enrollment of participants, three (4 percent) did not use consecutive enrollment76,79,93 and the remaining 23 studies were unclear. The majority of studies (n=55, 77 percent) adequately addressed incomplete outcome data. Seven studies69,116,131,142,160,175,187 had inadequate followup and nine were unclear.89,107,123,124,149,158,186,189,190 A standardized approach was used to assess outcomes in 29 studies (41 percent). Of the remaining studies, 31 (44 percent) were unclear and 11 used no standardized assessment approach.80,90,93,100,101,131,149,160,161,168,175

Source of funding was not reported in the majority of studies (n=44, 62 percent). No funding was received in 22 studies (31 percent).74,80,83,99,100,107,110,111,120–123,127,131,135,141,144,153,158,160,164,174 The remaining studies were supported through foundations,116,168,187 industry,193 or professional associations.175

## Results of Included Studies

This section is organized by the six key research questions addressed in this report. For each intervention category, the evidence from comparative studies (trials and cohorts) and uncontrolled studies is presented separately. A summary of key findings is provided, followed by a description of the characteristics and findings of the individual trials and cohort studies. Tables summarizing the general patient and summary characteristics, as well as the outcome data, are presented for each comparative study. In addition, a grading of the body of evidence is based on the comparative studies only and presented by key outcome. The uncontrolled studies are described in aggregate form and the results are presented visually for each intervention category. Appendix E presents detailed evidence tables on each of the included studies.

### Question 1. Early Surgical Repair vs. Late Surgical Repair

One RCT recently conducted by Moosmayer et al.66 provided data for the comparison of early vs. delayed surgical RCR (Tables 3-5). One hundred and three patients with small or medium-sized full-thickness RC tears were randomly assigned to nonoperative treatment consisting of manual techniques and exercises (n=51) or immediate surgical repair (n=52); 102 were followed for a minimum of 12 months. Nine of the patients initially randomized to nonoperative treatment were not satisfied with their degree of improvement after completing 15 treatment sessions, and were offered secondary surgery; these patients constituted the late surgery group. Health-related quality of life was assessed using the Short Form-36 Health Survey (SF-36) scale, while function was measured using the Constant-Murley score (CMS), the American Shoulder and Elbow Surgeons (ASES) index. In addition, cuff integrity was evaluated in the two surgical groups using magnetic resonance imaging (MRI). SF-36 scores were not reported for the secondary surgical group. Both the early and delayed surgical groups showed clinically important improvement from baseline to 12 month assessments. The improvement in the ASES score was similar between the early and late surgery groups (improvement of 47.1 and 46.8 points, respectively), however the improvement in the early surgical group was superior to the late surgical group on the CMS (improvement of 41.5 points and 33.6 points, respectively. The level of significance between these difference scores was not reported. Comparisons between the early surgery group and the nonoperative treatment arm are presented under Question 5 (nonoperative vs. operative treatment).

No other studies directly compared the effectiveness of early vs. late surgical repair of RC tears. However, a number of studies conducted a subgroup or regression analysis to assess whether time to surgery was a significant factor in predicting operative outcomes. Results of these studies are presented under Question 6 (prognostic variables).

Table 3 Study and patient characteristics for studies assessing early RCR vs. delayed RCR

Author, year | Intervention (N participants enrolled) Study design | Age (yr), mean±SD (range)/Males, N (%)Other characteristics | Type of tear; Size of tear Duration of symptoms (mo), mean±SD (range)
Moosmayer S,66 2010 | G1: PT (51) G2: Open/mini-open RCR (early) (52) G3: Secondary surgery (late) (9)^*^ RCT | G1: 61±7.6 yr/Males: 36 (71) G2: 59±7.5 yr/Males: 37 (71) G3: NR | FTT; Sm, Med G1: 9.8±9.8 mo; G2: 12.3±18.7 mo; G3: NR

FTT = full-thickenss tear; med = medium; mo = month; RCT = rotator cuff tear; SD = standard deviation; sm = small; yr = year

* Subset of patients who were initially randomized to PT, however later underwent secondary surgery due to lack of improvement; total sample size is 103 patients

Table 4 Outcome data for studies assessing early RCR vs. delayed RCR

Author, year | Intervention (N analysed) Followup, mean (range) | Outcome | Group 1 Baseline mean±SD (range)/Endpoint mean±SD (range) | Group 2/Group 3 Baseline mean±SD (range)/Endpoint mean±SD (range) | Group 1 vs. Group 2 p-value
Moosmayer S,66 2010 | G1: PT (51) G2: Open/mini-open repair (early) (51) G3: Secondary surgery (late) (9)^†^ 12 mo | SF-36 (95%CI) 6 mo 12 mo 6 mo 12 mo | PCSS: 38.6 (36.2–41.1) 47.3 (44.7–50.0) 48.9 (46.0–51.7), p=NR MCSS: 57.3 (54.7–59.9) 57.6 (55.5–59.7) 57.5 (55.4–59.5), p=NR | PCSS: 38.2 (36.6–39.9) 47.9 (45.3–50.4) 50.7 (47.8–53.6), p=NR MCSS: 54.1 (50.9–57.3) 57.5 (55.0–60.0) 56.2 (53.7–58.8), p=NR | G1 vs. G2: PCSS: 0.84>p>0.10^‡^ MCSS: 0.92>p>0.29^‡^ G2 vs. G3: NR
Moosmayer S,66 2010 | G1: PT (51) G2: Open/mini-open repair (early) (51) G3: Secondary surgery (late) (9)^†^ 12 mo | SF-36 (95%CI) 6 mo 12 mo 6 mo 12 mo | PCSS: 38.6 (36.2–41.1) 47.3 (44.7–50.0) 48.9 (46.0–51.7), p=NR MCSS: 57.3 (54.7–59.9) 57.6 (55.5–59.7) 57.5 (55.4–59.5), p=NR | G3: NR | G1 vs. G2: PCSS: 0.84>p>0.10^‡^ MCSS: 0.92>p>0.29^‡^ G2 vs. G3: NR
Moosmayer S,66 2010 | G1: PT (51) G2: Open/mini-open repair (early) (51) G3: Secondary surgery (late) (9)^†^ 12 mo | ASES*(95%CI) 6 mo 12 mo | 48.2 (44.1–52.2) 75.8 (70.2–81.4) 79.2 (72.7–85.5), p=NR | 45.5 (41.5–49.6) 84.5 (80.3–88.6) 92.6 (88.6–96.6), p=NR | G1 vs. G2: p<0.0005^‡^ G2 vs. G3: NR
Moosmayer S,66 2010 | G1: PT (51) G2: Open/mini-open repair (early) (51) G3: Secondary surgery (late) (9)^†^ 12 mo | ASES*(95%CI) 6 mo 12 mo | 48.2 (44.1–52.2) 75.8 (70.2–81.4) 79.2 (72.7–85.5), p=NR | G3: 42.1 (30.1–54.2) Pre-op§: 48.9 (32.6–65.2) 6 mo: 75.4 (59.2–91.7) 12 mo: 88.9 (77.4–100.0), p=NR | G1 vs. G2: p<0.0005^‡^ G2 vs. G3: NR
Moosmayer S,66 2010 | G1: PT (51) G2: Open/mini-open repair (early) (51) G3: Secondary surgery (late) (9)^†^ 12 mo | CMS* (95%CI) 6 mo 12 mo | 38.4 (34.4–42.4) 64.1 (58.5–69.7) 66.8 (60.6–73.1), p=NR | 35.3 (31.6–39.0) 64.9 (60.2–69.7) 76.8 (72.6–80.9), p=NR | G1 vs. G2: p=0.002^‡^ G2 vs. G3: NR
Moosmayer S,66 2010 | G1: PT (51) G2: Open/mini-open repair (early) (51) G3: Secondary surgery (late) (9)^†^ 12 mo | CMS* (95%CI) 6 mo 12 mo | 38.4 (34.4–42.4) 64.1 (58.5–69.7) 66.8 (60.6–73.1), p=NR | G3: 36.2 (27.3–45.2) Pre-op§: 35.9 (26.9–44.9) 6 mo: 57.9 (43.8–72.0) 12 mo: 69.8 (55.1–84.4), p=NR | G1 vs. G2: p=0.002^‡^ G2 vs. G3: NR
Moosmayer S,66 2010 | G1: PT (51) G2: Open/mini-open repair (early) (51) G3: Secondary surgery (late) (9)^†^ 12 mo | Cuff integrity n/N (%), MRI 12 mo | NR | 38/50 (76) \|\| | G1 vs. G2: NR G2 vs. G3: p=0.67^‡^
Moosmayer S,66 2010 | G1: PT (51) G2: Open/mini-open repair (early) (51) G3: Secondary surgery (late) (9)^†^ 12 mo | Cuff integrity n/N (%), MRI 12 mo | NR | G3: 8/9 (89) | G1 vs. G2: NR G2 vs. G3: p=0.67^‡^

ABD = abduction; ASES = American Shoulder and Elbow Surgeon score; CI = confidence interval; cm = centimetre; CMS = Constant-Murley Score; G = group; mo = month; MCSS = mental component summary score; MRI = magnetic resonance imaging; NR = not reported; PCSS = physical component summary score; PT = physical therapy; SF-36 = Short Form-36 Health Survey; VAS = visual analogue scale

Subscores reported

† Subset of patients who were initially randomized to PT, however later underwent secondary surgery due to treatment failure; total sample size is 103 patients

‡ Calculated by UAEPC

§ Score after failed PT, prior to surgery

|| One case was unable to undergo MRI

Table 5 Strength of evidence for early RCR vs. delayed RCR

Technique | Number of studies; subjects (analyzed)* | Outcome | Strength of evidence domains | | | | | Strength of evidence
| | | Risk of bias | Consistency | Directness | Precision | Confounding
Early vs. late RCR | 1; 103 (102) | HRQL | RCT Medium | Unknown | Direct | Unknown | Absent | Low
Early vs. late RCR | 1; 103 (102) | Function | RCT Medium | Unknown | Direct | Unknown | Absent | Low
Early vs. late RCR | 1; 103 (102) | Cuff integrity | RCT Medium | Unknown | Direct | Unknown | Absent | Low
Early vs. late RCR | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient

HRQL = health-related quality of life; n/a = not applicable; RCR = rotator cuff repair; RCT = randomized controlled trial

### Question 2. Comparative Effectiveness of Operative Interventions and Postoperative Rehabilitation

One hundred and thirteen studies examined the comparative effectiveness of operative interventions, while an additional eleven studies evaluated postoperative rehabilitation therapies. Studies assessing operative treatments were categorized as focusing on an operative approach (e.g., open, mini-open, arthroscopic, debridement), technique (i.e., suture or anchor type or configuration) or augmentations for RCR.

Overall, operative approaches were examined in 90 studies (32 comparative studies, 58 uncontrolled studies). Operative techniques were evaluated in 15 comparative studies. Augmentations for RCR were assessed in eight studies (three comparative studies, five uncontrolled studies). Eleven studies examined postoperative rehabilitation (10 comparative studies, one uncontrolled study).

#### Operative Approach—Comparative Studies

Summary. Thirty-two controlled studies making 13 comparisons assessed the effectiveness of different operative approaches for RCR. The following is a summary of results by comparison:

- One RCT136 and two retrospective cohort studies68,106 compared open RCR against mini-open RCR. Overall there was no statistically significant difference in function; however, the two cohort studies demonstrated significantly earlier return to work or sports by approximately 1 month for mini-open repairs. The individual studies showed no statistical or clinically important differences between groups for health-related quality of life, range of motion, or strength.
- Ten studies (one CCT,114 two prospective85,148 and seven retrospective cohort studies119,125,154,157,167,171,173) compared mini-open vs. arthroscopic RCR. All studies measured function and overall there was no difference between groups. However, heterogeneity was observed between the CCT and cohort studies, with the cohort studies showing more conservative results. Other outcomes were assessed across the studies and no differences were found for range of motion (n=5), strength (n=2), cuff integrity (n=2), and pain VAS (n=4). While the majority of these studies were retrospective cohorts, the studies were relatively well done and scored moderate or high on the relevant quality assessment instrument.
- One prospective112 and two retrospective cohort studies87,134 compared open RCR vs. arthroscopic RCR. Two prospective cohort studies72,77 compared open/mini-open RCR with arthroscopic RCR. There were no differences between the groups for function. One study77 found better pain relief for the group receiving arthroscopic repair than the open/mini-open group at final followup.
- Two CCTs137,143 and two retrospective cohort studies139,165 compared open RCR with open or arthroscopic debridement. Overall, improvement in function was significantly greater for open RCR. The magnitude of the difference varied across studies from an absolute difference of 2.2 on a 35-point scale143 to 11.5 on an 83-point scale;165 the cohort studies showed larger absolute differences than the trials. One of the cohort studies165 showed a significantly shorter time to maximum range of motion in the arthroscopic debridement group (3.2 vs. 6.8 months).
- Two RCTs102,133 compared arthroscopic RCR vs. arthroscopic RCR with acromioplasty, while one prospective cohort study140 compared arthroscopic RCR vs. acromioplasty alone. No differences in function were reported between the groups.
- Seven additional studies compared different operative approaches: biceps tenotomy vs. tenodesis,75 RCR vs. palliative treatment (partial repair or biceps tenotomy),94 arthroscopic RCR plus superior labral from anterior to posterior (SLAP) lesion repair vs. arthroscopic RCR plus biceps tenotomy,96 arthroscopic RCR plus tenodesis with proximal biceps detachment vs. without proximal biceps detachment,97 arthroscopic debridement with tenotomy vs. without tenotomy,63 complete open RCR vs. partial open RCR vs. debridement,138 and open RCR plus classic open acromioplasty vs. open RCR plus modified open acromioplasty.163 There were few clinically important differences between groups being compared across studies. No differences in function were observed for five of the comparisons.63,75,97,138,163 One study94 found a significant difference in function favouring RCR over palliative treatment. Another study96 showed greater postoperative University of Califonia Los Angeles (UCLA) index scores for arthroscopic RCR with biceps tenotomy compared with arthroscopic RCR plus SLAP repair; however, the absolute difference of 4 points on the 35-point scale is of questionable clinical importance.

Overall conclusions for operative approaches are challenging due to the wide variation in comparisons across studies. Generally, the studies showed few differences in function between interventions. One exception was greater improvement for open RCR compared with arthroscopic debridement; the strength of evidence for this finding was considered moderate. In addition, watertight anatomical repair was favoured for function compared with palliative treatment in patients with massive RC tears, and one small study96 suggested greater postoperative function for arthroscopic RCR with biceps tenotomy compared to arthroscopic RCR plus SLAP repair; the strength of evidence for these findings was low and needs replication in future studies before general conclusions can be made.

Results by individual study. Thirty-two comparative studies63,68,72,75,77,85,87,94,96,97,102,106,112,114,119,125,133,134,136–140,143,148,154,157,163,165,167,171,173 examined the effectiveness of different operative approaches for RCR. Five of the studies were RCTs, four were CCTs, six were prospective cohort designs, and 17 were retrospective cohort designs. The median sample size was 77 patients (IQR: 53 to 101). The following operative approaches were assessed: open vs. mini-open RCR,68,106,136 mini-open vs. arthroscopic RCR,85,114,119,125,148,154,157,167,171,173 open vs. arthroscopic RCR,87,112,134 open or mini-open RCR vs. arthroscopic RCR,72,77 open RCR vs. arthroscopic debridement,137,139,143,165 arthroscopic RCR vs. acromioplasty,102,133,140 biceps tenotomy vs. tenodesis,75 complete repair vs. palliative treatment (partial repair with biceps tenotomy),94 arthroscopic RCR with SLAP repair vs. arthroscopic RCR with biceps tenotomy,96 RCR with tenodesis with proximal biceps detachment vs. RCR with tenodesis without proximal biceps detachment,97 arthroscopic debridement with biceps tenotomy vs. without biceps tenotomy,63 complete open RCR vs. partial open RCR vs. debridement.138 open RCR with classic vs. modified acromioplasty.163 Five comparisons contained studies that were sufficiently similar in terms of conditions, interventions, and outcomes that meta-analysis was possible: open RCR vs. mini-open RCR, mini-open vs. arthroscopic RCR, open vs. arthroscopic RCR; open or mini-open RCR vs. arthroscopic RCR, and open RCR vs. arthroscopic debridement. Table 21 summarizes the rating of the body of evidence for operative approaches.

Table 21 Strength of evidence for operative approaches

Technique | Number of studies; subjects (analyzed)^*^ | Outcome | Strength of evidence domains | | | | | Strength of evidence
| | | Risk of bias | Consistency | Directness | Precision | Confounding
Open RCR vs. mini-open RCR | 1; 73 (60) | HRQL | RCT | Unknown | n/a | Imprecise | Absent | Low
Open RCR vs. mini-open RCR | 3; 187 (174) | Function | RCT, cohorts Medium | Consistent | Direct | Precise | Present | Moderate
Open RCR vs. mini-open RCR | 2; 114 | Cuff integrity | Cohorts Medium | Consistent | Direct | Precise | Present | Moderate
Open RCR vs. mini-open RCR | 2; 114 | Time to return to work | Cohorts Medium | Consistent | Direct | Precise | Present | Moderate
Mini-open RCR vs. arthroscopic RCR | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Mini-open RCR vs. arthroscopic RCR | 10; 768 (683) | Function | CCT, Cohorts Medium | Consistent | Direct | Precise | Present | Moderate
Mini-open RCR vs. arthroscopic RCR | 2; 204 (109) | Cuff integrity | Cohorts Medium | Consistent | Direct | Precise | Absent | Moderate
Mini-open RCR vs. arthroscopic RCR | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Open RCR vs. arthroscopic RCR | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Open RCR vs. arthroscopic RCR | 3; 296 (224) | Function | Cohorts Medium | Inconsistent | Direct | Imprecise | Absent | Low
Open RCR vs. arthroscopic RCR | 1; 159 (87) | Cuff integrity | Cohort Medium | Unknown | Direct | Imprecise | Absent | Low
Open RCR vs. arthroscopic RCR | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Open or mini-open RCR vs. arthroscopic RCR | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Open or mini-open RCR vs. arthroscopic RCR | 2; 198 (194) | Function | Cohorts Medium | Consistent | Direct | Imprecise | Absent | Moderate
Open or mini-open RCR vs. arthroscopic RCR | 1; 102 | Cuff integrity | Cohort Medium | Unknown | Direct | Imprecise | Absent | Low
Open or mini-open RCR vs. arthroscopic RCR | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Open RCR vs. open or arthroscopic debridement | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Open RCR vs. open or arthroscopic debridement | 4 | Function | RCT, CCT, Cohorts Medium | Consistent | Direct | Precise | Present | Moderate
Open RCR vs. open or arthroscopic debridement | 0 | Cuff integrity | Cohort Medium | Unknown | Direct | Imprecise | Present | Low
Open RCR vs. open or arthroscopic debridement | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Arthroscopic RCR vs. RCR plus acromioplasty | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Arthroscopic RCR vs. RCR plus acromioplasty | 2; 173 (164) | Function | RCTs, Cohort Medium | Consistent | Direct | Precise | Absent | Moderate
Arthroscopic RCR vs. RCR plus acromioplasty | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Arthroscopic RCR vs. RCR plus acromioplasty | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Arthroscopic RCR vs. acromioplasty alone | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Arthroscopic RCR vs. acromioplasty alone | 1; 210 | Function | Cohort Medium | Unknown | Direct | Imprecise | Absent | Low
Arthroscopic RCR vs. acromioplasty alone | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Arthroscopic RCR vs. acromioplasty alone | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Biceps tenotomy vs. tenodesis | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Biceps tenotomy vs. tenodesis | 1; 78 (68) | Function | RCT Medium | Unknown | Direct | Imprecise | Absent | Low
Biceps tenotomy vs. tenodesis | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Biceps tenotomy vs. tenodesis | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
RCR vs. palliative treatment | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
RCR vs. palliative treatment | 1; 192 | Function | Cohort Medium | Unknown | Direct | Unknown | Present | Low
RCR vs. palliative treatment | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
RCR vs. palliative treatment | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Arthroscopic RCR with SLAP repair vs. arthroscopic RCR with biceps tenotomy | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Arthroscopic RCR with SLAP repair vs. arthroscopic RCR with biceps tenotomy | 1; 63 | Function | RCT Medium | Unknown | Direct | Imprecise | Absent | Low
Arthroscopic RCR with SLAP repair vs. arthroscopic RCR with biceps tenotomy | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Arthroscopic RCR with SLAP repair vs. arthroscopic RCR with biceps tenotomy | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Arthoscopic RCR plus tenodesis with detachment vs. without detachment | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Arthoscopic RCR plus tenodesis with detachment vs. without detachment | 1; 22 | Function | RCT Medium | Unknown | Direct | Imprecise | Absent | Low
Arthoscopic RCR plus tenodesis with detachment vs. without detachment | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Arthoscopic RCR plus tenodesis with detachment vs. without detachment | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Arthroscopic debridement with vs. without biceps tenotomy | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Arthroscopic debridement with vs. without biceps tenotomy | 1; 41 | Function | Cohort Medium | Unknown | Direct | Imprecise | Absent | Low
Arthroscopic debridement with vs. without biceps tenotomy | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Arthroscopic debridement with vs. without biceps tenotomy | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Complete open RCR vs. partial open RCR vs. debridement | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Complete open RCR vs. partial open RCR vs. debridement | 1; 38 | Function | Cohort Medium | Unknown | Direct | Imprecise | Absent | Low
Complete open RCR vs. partial open RCR vs. debridement | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Complete open RCR vs. partial open RCR vs. debridement | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Open RCR with classic open vs. modified open acromioplasty | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Open RCR with classic open vs. modified open acromioplasty | 1; 42 | Function | CCT Medium | Unknown | Direct | Imprecise | Present | Low
Open RCR with classic open vs. modified open acromioplasty | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Open RCR with classic open vs. modified open acromioplasty | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient

CCT = controlled clinical trial; HRQL = health-related quality of life; n/a = not applicable; RCR = rotator cuff repair; RCT = randomized controlled trial; SLAP = superior labral tear from anterior to posterior

* number analyzed if different from number studied

Open vs. mini-open RCR. Three studies (one RCT136 and two cohort studies68,106) compared open RCR against mini-open RCR. Pooled results are shown in Figure 3 and Figure 4. Patient and study characteristics and outcome data are presented in Table 6 and Table 7, respectively.

Figure 3 Open vs. mini-open RCR on measures of functional outcome

Forest plot showing that one RCT and two cohort studies provided data for a meta-analysis of the effects of open versus mini-open RCR on functional outcome measures. Data from the trial at various time points (3, 6, 12, 24 months) and two cohorts is presented separately. The ASES is presented for the RCT, while the cohort studies both used the UCLA score. For all studies, mean change scores between preoperative and postoperative scores were compared between groups. The combined estimate of change in function for the cohort studies shows no significant difference between the interventions, yet favors mini-open repair (SMD=-0.40; 95% CI, -0.95 to 0.15). There was moderate heterogeneity between the studies (p=0.16; I2=49 percent).

Figure 4 Open vs. mini-open RCR on time to return to work

Forest plot showing that data from two cohort studies was pooled for time to return to work. The pooled estimate indicates significantly shorter time to return to work for the mini-open RCR group compared with the open RCR group (mean difference=1.08; 95% CI, 0.63 to 1.52). There was no evidence of heterogeneity between the two studies (p=0.85, I2=0 percent).

Table 6 Study and patient characteristics for studies assessing open vs. mini-open RCR

Author, year | Intervention (N participants enrolled) Study design | Age (yr), mean±SD (range)/Males, N (%) Other characteristics | Type of tear; Size of tear Duration of symptoms (mo), mean±SD (range)
Baker CL,68 1995 | G1: Open RCR (20) G2: Mini-open RCR (16) Retrospective cohort | G1: 62 yr (38–81)/Males: 12 (60) Athletes: 4 (20) Manual laborers: 6 (30) G2: 59 yr (41–71)/Males: 9 (56) Athletes: 4 (25) Manual laborers: 5 (31) | FTT; Sm, Med, Lg NR
Hata Y,106 2004 | G1: Open RCR (43) G2: Mini-open RCR (35) Retrospective cohort | G1: 58.1 yr (31–78)/Males: 25 (58) G2: 60.6 yr (39–71)/Males: 21 (60) | NR; Sm, Med, Lg NR
Mohtadi NG,136 2008 | G1: Open RCR (37) G2: Mini-open RCR (36) RCT | G1: 56.2 yr (44–77)/Males: 22 (60) G2: 57 yr (33–82)/Males: 20 (55) | FTT; Sm, Med, Lg, Mass >3 mo

FTT = full-thickness tear; G = group; Lg = large; Mass = massive; Med = medium; NR = not reported; RCR = rotator cuff repair; RCT = randomized controlled trial; SD = standard deviation; Sm = small

Table 7 Outcome data for studies assessing open vs. mini-open RCR

Author, year | Intervention (N analysed) Followup, mean (range) | Outcome | Group 1 Baseline mean±SD (range)/Endpoint mean±SD (range) | Group 2 Baseline mean±SD (range)/Endpoint mean±SD (range) | Group 1 vs. Group 2 p-value
Baker CL,68 1995 | G1: Open RCR (20) G2: Mini-open RCR (16) 3.3 yr | UCLA^*^ | 9.1/31.2, p≤0.05 | 10.5/32.7, p≤0.05 | p>0.05
Baker CL,68 1995 | G1: Open RCR (20) G2: Mini-open RCR (16) 3.3 yr | Time to return to work (mo) | 5.6 (4.2–7.2) | 4.5 (3.7–6.5) | NR
Baker CL,68 1995 | G1: Open RCR (20) G2: Mini-open RCR (16) 3.3 yr | ROM (degrees) | F: 99/153, p≤0.05 ER: 30/155, p≤0.05 ABD: 96/47, p≤0.05 | F: 104/161, p≤0.05 ER: 34/49, p≤0.05 ABD: 100/159, p≤0.05 | p>0.05 p>0.05 p>0.05
Baker CL,68 1995 | G1: Open RCR (20) G2: Mini-open RCR (16) 3.3 yr | Strength | F: 2.4/4.5, p≤0.05 ER: 3/4.2, p≤0.05 ABD: 3.2/4.4, p≤0.05 | F: 2.7/4.6, p≤0.05 ER: 2.9/4.8, p≤0.05 ABD: 3.4/4.7, p≤0.05 | NR NR p=0.002
Baker CL,68 1995 | G1: Open RCR (20) G2: Mini-open RCR (16) 3.3 yr | Cuff integrity n/N (%), arthrography | 10/20 shoulders (50) | 9/17 shoulders (52.9) | p=1.0^‡^
Hata Y,106 2004 | G1: Open RCR (43) G2: Mini-open RCR (35) 4 yr (2–6.8) | UCLA^*^ 2 yr | 14.3 (6–26)/33.0, p<0.01 | 13.8 (6–26)/33.4, p<0.01 | p>0.05^†^
Hata Y,106 2004 | G1: Open RCR (43) G2: Mini-open RCR (35) 4 yr (2–6.8) | Time to return to work (mo) | 3.4 | 2.4 | p≤0.05
Hata Y,106 2004 | G1: Open RCR (43) G2: Mini-open RCR (35) 4 yr (2–6.8) | Cuff integrity n/N (%), MRI 12 mo | 0/43 (0) | 0/35 (0) | NA
Mohtadi NG,136 2008 | G1: Open RCR (29) G2: Mini-open RCR (31) 2 yr | RC-QOL 3 mo 6 mo 12 mo 2 yr | 40.9 (95% CI, 35.5–46.2) 55.6 (47.5–63.7) 72.4 (65.0–79.8) 85.0 (79.2–90.8) 86.9 (81.8–92.0) | 45.5 (95% CI, 38.5–52.5) 71.3 (63.8–78.9) 82.3 (78.3–86.3) 88.5 (84.1–92.9) 87.2 (80.6–93.8) | p=0.005 p=0.015 p=0.34 p=0.94
Mohtadi NG,136 2008 | G1: Open RCR (29) G2: Mini-open RCR (31) 2 yr | ASES 3 mo 6 mo 12 mo 2 yr | 48.2 (95% CI, 40.7–55.6) 61.8 (54.8–68.7) 68.9 (61.7–76.1) 85.2 (79.5–90.9) 87.5 (81.9–93.1) | 53.8 (95% CI, 47.1–60.5) 71.8 (64.4–79.1) 80.7 (74.2–87.3) 86.1 (79.9–92.2) 89.9 (85.4–94.4) | p=0.048 p=0.016 p=0.84 p=0.94
Mohtadi NG,136 2008 | G1: Open RCR (29) G2: Mini-open RCR (31) 2 yr | SRQ 3 mo 6 mo 12 mo 2 yr | 46.7 (95% CI, 41.3–52.1) 63.3 (57.5–69.1) 73.6 (68.2–79.1) 83.4 (78.1–88.8) 85.1 (80.2–90.1) | 50.3 (95% CI, 45.2–55.4) 69.4 (62.6–76.3) 79.8 (74.7–84.9) 85.2 (81.2–89.2) 85.9 (81.7–90.0) | p=0.170 p=0.096 p=0.587 p=0.806
Mohtadi NG,136 2008 | G1: Open RCR (29) G2: Mini-open RCR (31) 2 yr | ROM(degrees) 12 mo | F: 147.7±35.1/162.3±19.2 ER on side: 46.1±15.3/54.1±28.6 ER at 90^o^: 73.1±27.6/78.4±16.7 IR^§^ (range): 2.3 (−1– +9)/1.2 (−5– +7) | F: 155.2±35.2/158.3±22.61 ER on side: 46.6±22.3/48.1±29.7 ER at 90^o^: 78.8±16.8/79.0±13.6 IR^§^ (range, n): 3.0 (−3 –+12)/0.96 (−5–+5) | F: p=0.46^‡^ ER on side: p=0.43^‡^ ER at 90^o^: p=0.88^‡^
Mohtadi NG,136 2008 | G1: Open RCR (29) G2: Mini-open RCR (31) 2 yr | FSET 6 mo 12 mo | 31.4 (19.2–43.6) (95% CI) 53.4 (35.7–71.1) 74.8 (61.0–88.5) | 34.1 (21.6–46.6) (95% CI) 58.7 (46.0–71.4) 75.9 (63.3–88.5) | p=0.601 p=0.899

ABD = abduction; ASES = American Shoulder and Elbow Scale; ER = external rotation; F = flexion; FSET = functional shoulder elevation test; G = group; IR = internal rotation; mo = month; MRI = magnetic resonance imaging; N = number; NA = not applicable; NR = not reported; RCR = rotator cuff repair; RC-QOL = rotator cuff quality of life scale; ROM = range of motion; SD = standard deviation; SRQ = Shoulder Rating Questionnaire; UCLA = University of California Los Angeles Scale

* Subscales reported;

† No significant differences were detected between groups at 3, 6, 12 mo or 2 yr;

‡ Calculated by UAEPC;

§ Vertebral level, involved-uninvolved difference

Mohtadi et al.136 conducted a RCT in patients with small to massive full-thickness tears. Seventy-three patients were randomly assigned to the interventions (37 to open surgical repair and acromioplasty, 36 to mini-open repair with arthroscopic acromioplasty) and 60 were followed up for at least 2 years. Patient quality of life was assessed using the RC-QOL and function was assessed using the ASES, Shoulder Rating Questionnaire (SRQ), range of motion (flexion, external and internal rotation), and functional shoulder elevation test (FSET). At the 2-year followup, mean RC-QOL score had improved for both groups, but the differences were not statistically significant (p=0.94). Mean ASES and SRQ scores had improved for both groups, but there was no statistically significant differences between the postoperative scores (p=0.94 and p=0.806, respectively). Range of motion and FSET were assessed at 12 months. Both groups showed some improvement in range of motion measures at 12 months; however, the difference between groups was not statistically significant. Both groups also showed improvement in FSET scores; however, the differences in postoperative scores were not statistically significant (p=0.899).

Baker et al.68 conducted a retrospective cohort study in patients with small, medium, and large full-thickness tears. Thirty-six patients were evaluated (20 received open repair with acromioplasty, 16 received mini-open repair with arthroscopic acromioplasty), and all patients were followed for at least 2 years. The mean followup was 3.3 years. Patients were evaluated using the UCLA score, range of motion (flexion, external rotation, and abduction), strength (flexion, external rotation, and abduction), and time to return to work. At final postoperative followup, the two groups both demonstrated improvement in the UCLA score and range of motion, but the difference between the two groups was not statistically significant (p>0.05). Strength scores also improved from baseline to endpoint, however there were no significant differences between the groups at endpoint except in abduction strength (p=0.002), which favored mini-open repair. The mean time to return to work was 5.6 months (range: 4.2 to 7.2) for the open repair group and 4.5 months (range: 3.7 to 6.5) for the mini-open group. Cuff integrity was examined at final followup using arthrography. In the open RCR group, 10 patients (50 percent) had an intact cuff, compared with nine patients (52.9 percent) in the mini-open group. There was no significant difference between the groups for cuff integrity.

Hata et al.106 conducted a retrospective cohort study in patients with small, medium, and large RC tears. Seventy-eight patients were evaluated (43 received open repair with acromioplasty, 35 received mini-open repair with acromioplasty), and all patients were followed for at least 2 years. The mean followup was 4 years. Patient function was assessed using the UCLA score and time to return to work. At the 2-year followup, mean UCLA score improved for both groups; however, the difference between the postoperative scores was not statistically significant. For the mini-open group, the mean time to return to work or sports activities (2.4 months) was significantly shorter than in the open repair group (3.4 months) (p≤0.05). Cuff integrity was examined at 12 months using MRI. No ruptures were detected in either group.

One RCT136 and two cohort studies68,106 provided data for a meta-analysis of the effects of open vs. mini-open RCR on functional outcome measures (Figure 3). Data from the trial at various time points (3, 6, 12, 24 months) and two cohorts is presented separately. The ASES is presented for the RCT,136 while the cohort studies both used the UCLA score. For all studies, mean change scores between preoperative and postoperative scores were compared between groups. The combined estimate of change in function for the cohort studies shows no significant difference between the interventions, yet favors mini-open repair (SMD=−0.40; 95% CI, −0.95 to 0.15). There was moderate heterogeneity between the studies (p=0.16; I2=49 percent). Differences in the patient population may account for some of the heterogeneity between studies, since the study population for Baker et al.68 included a substantial proportion of both recreational athletes and manual laborers.

Data from two cohort studies68,106 was pooled for time to return to work (Figure 4). The pooled estimate indicates significantly shorter time to return to work for the mini-open RCR group compared with the open RCR group (mean difference=1.08 months; 95% CI, 0.63 to 1.52 months). There was no evidence of heterogeneity between the two studies (p=0.85, I2=0 percent).

Mini-open vs. arthroscopic RCR. Ten studies (one CCT,114 two prospective cohort studies85,148 and seven retrospective cohort studies119,125,154,157,167,171,173) compared mini-open RCR against arthroscopic RCR. Pooled results are shown in Figure 5 and Figure 6. Patient and study characteristics and outcome data are presented in Table 8 and Table 9, respectively.

Figure 5 Mini-open vs. arthroscopic RCR on measures of functional outcome

Forest plot showing that one CCT and nine cohort studies (two prospective and seven retrospective) provided data for meta-analysis of the effects of mini-open versus arthroscopic repair on functional outcome measures. Data from the trial and cohort studies was analyzed separately. The following outcome measures were included in the meta-analysis: ASES, CMS, DASH, SST, and the UCLA. The mean change between preoperative and postoperative scores was compared for four studies. The remaining studies provided no baseline data, therefore the endpoint scores are compared between groups. There were no significant differences between the mini-open and arthroscopic repair groups on functional outcome measures, either for the one CCT or the pooled estimate of nine cohort studies. The CCT favored mini-open repair (MD=0.32; 95% CI, -0.13 to 0.78). The combined estimate of functional outcomes from cohort studies slightly favored arthroscopic repair (SMD=-0.11, 95% CI, -0.28 to 0.06) There was no evidence of heterogeneity between the pooled studies (p=0.67; I2=0 percent).

Figure 6 Mini-open vs. arthroscopic RCR on cuff integrity

Forest plot showing that two cohort retrospective studies provided data for meta-analysis of the effects of mini-open versus arthroscopic repair on cuff integrity. The pooled estimate of effect showed no significant difference between the surgical approaches on the proportion of patients with intact RCs, however there was a trend favoring arthroscopic RCR (relative risk=0.80; 95% CI, 0.62 to 1.02). There was no evidence of heterogeneity between the two studies (p=0.44, I2=0 percent).

Table 8 Study and patient characteristics for studies assessing mini-open vs. arthroscopic RCR

Author, year | Intervention (N participants enrolled) Study design | Age (yr), mean±SD (range)/Males, N (%)Other characteristics | Type of tear; Size of tear Duration of symptoms(mo), mean±SD(range)
Colegate-Stone T,85 2009 | G1: Mini-open RCR (31) G2: Arthroscopic RCR (92) Prospective cohort | G1: 62 yr/Males: 16 (52) G2: 57 yr/Males: 44 (48) | NR; G1: >30 mm, G2: <30 mm
Kim SH,114 2003 | G1: Mini-open RCR (NR) G2: Arthroscopic RCR (NR) CCT | G1: 58±9 yr (42–68)/Males: 22 (65) G2: 55±10.5 yr (42–75)/Males: 27 (64) | FTT; Med, Lg NR
Kose KC,119 2008 | G1: Mini-open RCR (NR) G2: Arthroscopic RCR (NR) Retrospective cohort | G1: 62±10 yr (32–75)/Males: 4 (16) G2: 55±7.6 yr (34–72)/Males: 7 (28) | NR; Sm, Med, Lg NR
Liem, D,125 2007 | G1: Mini-open RCR (24) G2: Arthroscopic RCR (53) Retrospective cohort | G1: 62.9±6.7 yr/Males: 16 (67) G2: 61.9±6.6 yr/Males: 16 (30) | NR; Sm, Med, Lg G1:10.6±7.9 mo, G2: 9.6±5.2 mo
Pearsall AW,148 2007 | G1: Mini-open RCR (NR) G2: Arthroscopic RCR (NR) Prospective cohort | G1: 58 yr (41–76)/Males: 10 (40) WCB: 0; Smokers: 8 (32) G2: 55 yr (38–78)/Males: 11 (41) WCB: 0; Smokers: 3 (11) | FTT; Med, Lg NR
Sauerbrey AM,154 2005 | G1: Mini-open RCR (NR) G2: Arthroscopic RCR (NR) Retrospective cohort | G1: 57 yr (40–84)/Males: 16 (62) Athletes: 16 (62) G2: 56 yr (38–86) / Males: 16 (57) Athletes: 9 (32) | FTT; Med, Lg, Mass NR
Severud EL,157 2003 | G1: Mini-open RCR (NR) G2: Arthroscopic RCR (NR) Retrospective cohort | G1: 63.3 yr/Males: 18 (62) WCB: 3 (10) G2: 58.7 yr/Males: 21 (60) WCB: 6 (17) | FTT/PTT; Sm, Med, Lg G1: 10.8 mo, G2: 15.7 mo
Verma NN,167 2006 | G1: Mini-open RCR (58) G2: Arthroscopic RCR (69) Retrospective cohort | G1: 60.7±10.4 yr/Males: 23 (40) G2: 59.5±8.6 yr/Males: 22 (32) | FTT; Sm, Med, Lg, Mass NR
Warner JJ,171 2005 | G1: Mini-open RCR (12) G2: Arthroscopic RCR (9) Retrospective cohort | G1: 55±8 yr/Males: 8 (67) WCB: 1 (8) G2: 53±10 yr/Males: 5 (56) WCB: 0 (0) | FTT; NR G1: 9±4 mo, G2: 12±4mo
Youm T,173 2005 | G1: Mini-open RCR (NR) G2: Arthroscopic RCR (NR) Retrospective cohort | G1: 60 yr/NR G2: 57.9 yr/NR | NR; Sm, Med, Lg NR

CCT = controlled clinical trial; FTT = full-thickness tear; G = group; Lg = large; Mass = massive; Med = medium; N = number; NR = not reported; PTT = partial-thickness tear; RCR = rotator cuff repair; SD = standard deviation; Sm = small; WCB = workers’ compensation board

Table 9 Outcome data for studies assessing mini-open vs. arthroscopic RCR

Author, year | Intervention (N analysed) Followup, mean (range) | Outcome | Group 1 Baseline mean±SD (range)/ Endpoint mean±SD (range) | Group 2 Baseline mean±SD (range)/ Endpoint mean±SD (range) | Group 1 vs. Group 2 p-value
Colegate-Stone T,85 2009 | G1: Mini-open RCR (NR) G2: Arthroscopic RCR(NR) 2 yr | CMS 3 mo 6 mo 12 mo 24 mo | 33.7 46.1 47.4 54.0 75.1,^‡^ p<0.05 | 44.8 52.2 60.1 73.3 97.6,^‡^ p<0.05 | p>0.05 p>0.05 p>0.05 p≤0.05
Colegate-Stone T,85 2009 | G1: Mini-open RCR (NR) G2: Arthroscopic RCR(NR) 2 yr | DASH 3 mo 6 mo 12 mo 24 mo | 66.3 52.1 50.4 42.1 34.5,^‡^ p<0.05 | 53.5 53.4 35.3 33.0 28.1,^‡^ p<0.05 | p>0.05
Colegate-Stone T,85 2009 | G1: Mini-open RCR (NR) G2: Arthroscopic RCR(NR) 2 yr | OSS 3 mo 6 mo 12 mo 24 mo | 42.4 41.3 29.3 28.8 23.3,^‡^ p<0.05 | 37.1 32.5 24.3 25.6 14.2,^‡^ p<0.05 | p>0.05
Kim SH,114 2003 | G1: Mini-open RCR (34) G2: Arthroscopic RCR (42) 3.3 yr (2.0–5.3) | ASES | 59±12 (30–80)/95±7.3 (75–100), p<0.001 | 61±16 (34–87)/95±7.2 (75–100), p<0.001 | p=0.67
Kim SH,114 2003 | G1: Mini-open RCR (34) G2: Arthroscopic RCR (42) 3.3 yr (2.0–5.3) | UCLA | 18±2.6 (12–22)/33±3.4 (25–35), p<0.001 | 19±4.3 (12–26)/33±2.8 (26–35), p<0.001 | p=0.65
Kim SH,114 2003 | G1: Mini-open RCR (34) G2: Arthroscopic RCR (42) 3.3 yr (2.0–5.3) | Percent Function(VAS) | 54±12 (30–80)/93±8.3 (70–100), p<0.001 | 57±16 (20–80) / 93±8.8 (70–100), p<0.001 | p=0.99
Kim SH,114 2003 | G1: Mini-open RCR (34) G2: Arthroscopic RCR (42) 3.3 yr (2.0–5.3) | Pain (VAS) | 3.2±1.6 (1–6)/1.0±1.5 (0–6), p<0.001 | 4.2±2.5 (1–8) / 0.7±1.1 (0–5), p<0.001 | p=0.81
Kim SH,114 2003 | G1: Mini-open RCR (34) G2: Arthroscopic RCR (42) 3.3 yr (2.0–5.3) | ROM (degrees) | F: 30±26 (0–130)/4.0±6.9 (0–25), p<0.001 ER: 16±19 (0–35)/1.3±2.6 (0–10), p<0.001 IR: 4±2.6 (0–8)/0.6±1.2 (0–4), p<0.001 | F: 27±21 (0–110)/3.2±6.8 (0–25), p<0.001 ER: 12±18 (0–35)/1.1±2.6 (0–10), p<0.001 IR: 4±3.2 (0–9)/0.4±0.9 (0–3), p<0.001 | F: p=0.51 ER: p=0.50 IR: p=0.31
Kim SH,114 2003 | G1: Mini-open RCR (34) G2: Arthroscopic RCR (42) 3.3 yr (2.0–5.3) | Strength grade(gr), manual muscle testing, n (%) | gr 5: 9 (27)/25 (73), p<0.001 gr 4: 17 (50)/6 (18) gr 3: 8 (23)/3 (9) | gr 5: 11 (26)/35 (83), p<0.001 gr 4: 24 (57)/4 (10) gr 3: 7 (18)/3 (7) | p=0.33
Kose KC,119 2008 | G1: Mini-open RCR (25) G2: Arthroscopic RCR (25) 2.2 yr (12 mo–6.8 yr) | CMS^*^ | 45.6±12.4/79.56±13.64, p<0.01 | 46.2±11.8/83.56±11.45, p<0.01 | p=0.24
Kose KC,119 2008 | G1: Mini-open RCR (25) G2: Arthroscopic RCR (25) 2.2 yr (12 mo–6.8 yr) | UCLA^*^ | 10.6±4.5/28.8±3.42, p<0.01 | 11.2±5.6/29.76±4.5, p<0.01 | p=0.63
Liem D,125 2007 | G1: Mini-open RCR (19) G2: Arthroscopic RCR (19) 12 mo (minimum) | CMS^*^ | 53.5 / 83.7, p=0.0001 | 53.8/83.9, p=0.0001 | NR
Liem D,125 2007 | G1: Mini-open RCR (19) G2: Arthroscopic RCR (19) 12 mo (minimum) | ROM (degrees) | F: 154 / 175, p=0.01 ABD: 148 / 164, p=0.22 ER: 52 / 56, p=0.43 | F: 155/176, p=0.006 ABD: 149/173, p=0.016 ER: 47/59, p=0.011 | p>0.05
Liem D,125 2007 | G1: Mini-open RCR (19) G2: Arthroscopic RCR (19) 12 mo (minimum) | Cuff integrity n/N (%), MRI | 12/19 (63.1) | 13/19 (68.4) | p=1.0^†^
Pearsall AW,148 2007 | G1: Mini-open RCR (25) G2: Arthroscopic RCR (27) 4.2 yr (2.3–7) | UCLA | NR / 27 | NR/24 | p=0.34 G1+G2: pre-op vs. post-op: p<0.0001
Pearsall AW,148 2007 | G1: Mini-open RCR (25) G2: Arthroscopic RCR (27) 4.2 yr (2.3–7) | SST improvement | NR / 4.7 | NR/5.1 | p=0.66 G1+G2: pre-op vs. post-op: p<0.0001
Pearsall AW,148 2007 | G1: Mini-open RCR (25) G2: Arthroscopic RCR (27) 4.2 yr (2.3–7) | Pain improvement(VAS) | NR / 4.8 | NR/3.9 | p=0.29 G1+G2: pre-op vs. post-op: p<0.0001
Pearsall AW,148 2007 | G1: Mini-open RCR (25) G2: Arthroscopic RCR (27) 4.2 yr (2.3–7) | ROM Improvement(degrees) | F (active): NR / 18 ABD (active): NR / 14 GH: NR / 7.0 ER @ 0: NR / 12 ER @ 90: NR / 16 IR @ 90: NR / 11 | F (active): NR/35 ABD (active): NR/21 GH: NR/8.3 ER @ 0: NR/11 ER @ 90: NR/19 IR @ 90: NR/8 | p=0.16 p=0.18 p=0.7 p=0.7 p=0.7 p=0.7 | G1+G2: pre- op vs. post-op: p=0.01 p=0.07 p=0.01 p=0.03 p=0.001 p=0.14
Sauerbrey AM,154 2005 | G1: Mini-open RCR (26) G2: Arthroscopic RCR (28) 2.1 yr (13 mo–4 yr) | ASES^*^ | 52 (17–75) / 89 (56–100), p≤0.05 | 42 (9–47)/86 (43–100), p≤0.05 | p=0.33
Severud EL,157 2003 | G1: Mini-open RCR (29 shoulders) G2: Arthroscopic RCR (35 shoulders) 3.7 yr (2–6.8) | ASES | NR / 90.0 | NR/91.7 | p>0.05
Severud EL,157 2003 | G1: Mini-open RCR (29 shoulders) G2: Arthroscopic RCR (35 shoulders) 3.7 yr (2–6.8) | UCLA | NR/31.4 | NR/32.6 | p>0.05
Verma NN,167 2006 | G1: Mini-open RCR (33) G2: Arthroscopic RCR (38) 3.2 yr (2–8.1) | ASES | NR/95.1±9.3 | NR/94.6±8.9 | p>0.05
Verma NN,167 2006 | G1: Mini-open RCR (33) G2: Arthroscopic RCR (38) 3.2 yr (2–8.1) | Insalata | NR / 94.2±8.8 | NR/92.7±9.0 | p>0.05
Verma NN,167 2006 | G1: Mini-open RCR (33) G2: Arthroscopic RCR (38) 3.2 yr (2–8.1) | SST | NR / 11.3±1.4 | NR/11.4±0.9 | p>0.05
Verma NN,167 2006 | G1: Mini-open RCR (33) G2: Arthroscopic RCR (38) 3.2 yr (2–8.1) | Pain (VAS) | NR / 0.4±1.0 | NR/0.7±1.2 | p>0.05
Verma NN,167 2006 | G1: Mini-open RCR (33) G2: Arthroscopic RCR (38) 3.2 yr (2–8.1) | ROM (degrees) | F: NR / 169.4± 6.9 ABD: NR / 168.9± 8.4 ER: NR / 70.2±14.4 IR: NR / 9.2±3.1 | F: NR/170.5±6.9 ABD: NR/169.6±7.5 ER: NR/68.2±16.7 IR: NR/9.8±3.1 | p>0.05
Verma NN,167 2006 | G1: Mini-open RCR (33) G2: Arthroscopic RCR (38) 3.2 yr (2–8.1) | Cuff integrity n/N (%) | 17/25 (68.0) | 20/22 (90.9) | p=0.079^†^
Warner JJ,171 2005 | G1: Mini-open RCR (12) G2: Arthroscopic RCR (9) 4.2±1.3 yr (2.3–7.1) | SST | NR/12 (9–12) | NR/12 (5–12) | p=0.28
Warner JJ,171 2005 | G1: Mini-open RCR (12) G2: Arthroscopic RCR (9) 4.2±1.3 yr (2.3–7.1) | Pain (VAS) | 7 (6–9)/0 (0–2), p<0.01 | 7 (5–8)/0 (0–2), p<0.01 | p=0.92
Warner JJ,171 2005 | G1: Mini-open RCR (12) G2: Arthroscopic RCR (9) 4.2±1.3 yr (2.3–7.1) | ROM (degrees) | F: 150 (30–160)/155 (110–170), p>0.2 ER: 50 (30–50)/50 (25–60), p>0.2 | F: 145 (120–160)/160 (130–170), p>0.2 ER: 50 (40–60)/50 (30–60), p>0.2 | F: p=0.25 ER: p=0.80
Warner JJ,171 2005 | G1: Mini-open RCR (12) G2: Arthroscopic RCR (9) 4.2±1.3 yr (2.3–7.1) | Strength grade | 4 (2–5)/4 (4–5), p=0.26 | 4 (3–5)/5 (4–5), p<0.01 | p=0.08
Youm T,173 2005 | G1: Mini-open RCR (42) G2: Arthroscopic RCR (42) 3.0 yr (2.0–5.8) | ASES | NR/90.2±14.8 | NR/91.1±15.4 | p>0.05
Youm T,173 2005 | G1: Mini-open RCR (42) G2: Arthroscopic RCR (42) 3.0 yr (2.0–5.8) | UCLA | NR/32.3±3.3 | NR/33.2±2.5 | p>0.05

ABD = abduction; ASES = American Shoulder and Elbow Scale; CMS = Constant-Murley score; ER = external rotation; F = flexion; G = group; GH = glenohumeral elevation; gr = grade; IR = internal rotation; Insalata = Insalata Shoulder Rating Questionnaire; mo = month; MRI = magnetic resonance imaging; NR = not reported; OSS = Oxford Shoulder Score; pre-op = preoperative; post-op = postoperative; RCR = rotator cuff repair; ROM = range of motion; SD = standard deviation; SST = simple shoulder test; UCLA = University of California Los Angeles Scale; VAS = visual analogue scale; yr = year

* Subscores reported

† Calculated by UAEPC;

‡ Data extrapolated from graph

Colgate-Stone and colleagues85 compared mini-open vs. arthroscopic RCR in a prospective cohort study. Patients with tear sizes exceeding 30 mm underwent mini-open repair (n=31), while those with tears less than 30 mm were treated with arthroscopic repair (n=92). Patients were followed for 24 months and were evaluated using the CMS, the DASH and the Oxford Shoulder Score. In both groups, scores significantly improved between baseline and endpoint. There was a significant difference between the groups at 12 months (p≤0.05), yet not at 3, 6 or 24 months.

Kim et al.114 conducted a CCT in patients with medium or large full-thickness tears. Seventy-six patients were analyzed in the two treatments (34 received mini-open repair with acromioplasty, 42 received all-arthroscopic repair with acromioplasty) and were followed for at least 2 years. The mean followup was 3.3 years (2.0 to 5.3 years). Patients were evaluated on ASES and UCLA scores, percent function on a visual analogue scale, pain, range of motion, and strength. Shoulder scores improved in all ratings in both groups (p 0≤05) at followup; however, no statistically significant differences were seen between the two groups at study endpoint (p>0.05).

Kose et al.119 conducted a retrospective cohort study with patients with small, medium, and large tears. Fifty-seven patients were selected and 50 evaluated (25 received mini-open repair with acromioplasty, 25 received arthroscopic repair with acromioplasty) at 2.2 years (range: 12 months to 6.8 years). Patients’ function was evaluated using the Constant-Murley Score (CMS) and UCLA score. The improvements between pre- and postoperative CMS and UCLA scores were statistically significant within both groups (p<0.01); however, the difference in postoperative scores between the two groups was not significant (p=0.24 and p=0.63, respectively).

Liem et al.125 conducted a retrospective cohort study of patients with small, medium, and large tears. Seventy-seven patients were selected and 38 evaluated (19 received mini-open repair with acromioplasty, 19 received arthroscopic repair with acromioplasty) at a minimum of 12 months. Patient function was evaluated using the CMS and early range of motion (flexion, abduction, and external rotation). At followup, both groups showed statistically significant improvement in the CMS (p=0.0001) and for all range of motion tests, except abduction and external rotation in the open RCR group. However, the between group differences in all scores were not statistically significant. Cuff integrity was evaluated at followup using MRI. Seven patients in the mini-open group and six in the all-arthroscopic group experienced retears; the difference between the groups was not statistically significant.

In a prospective cohort study, Pearsall et al.148 compared mini-open vs. arthroscopic repair among patients with medium and large full-thickness tears. Fifty-two (25 receiving mini-open repair, 27 receiving arthrscopic repair) of the 54 patients enrolled were evaluated using the UCLA, Simple Shoulder Test (SST), pain visual analogue scale, and range of motion. There was statistically significant improvement in all outcomes from baseline to a mean followup of 4.2 years, however no significant differences between the two groups for any outcome measure.

Sauerbrey et al.154 conducted a retrospective cohort study in patients with medium, large, and massive full-thickness tears. Sixty-three patients were selected and 54 evaluated (26 received mini-open repair with acromioplasty, 28 received all-arthroscopic repair with acromioplasty) at 2.1 years (range: 13 months to 4 years). At followup, both groups showed significant improvement in ASES score (p<0.05); however, the difference between postoperative scores was not statistically significant (p=0.33).

Severud et al.157 conducted a retrospective cohort study with patients with small, medium, and large partial- and full-thickness tears. Sixty-four of 82 enrolled shoulders were evaluated (29 shoulders received mini-open repair with subacromial decompression, 35 received all-arthroscopic repair with subacromial decompression) at a minimum of 24 months. The mean followup time was 3.7 years (range: 2 to 6.8 years). Patient function was evaluated using the ASES and UCLA scores. At followup, there were no statistically significant differences between the groups for either ASES or UCLA scores.

Verma et al.167 conducted a retrospective cohort study with patients with small and large full-thickness tears. One hundred twenty-seven patients were selected (58 received mini-open repair with acromioplasty, 69 received arthroscopic repair with acromioplasty), of which 71 were evaluated at a minimum of 2 years. The mean followup was 3.2 years (range: 2 to 8.1 years). Patient function was assessed using the ASES, Insalata, and SST. Pain on a visual analogue scale and range of motion were also assessed. Preoperative and postoperative measures were not compared for any outcome. At followup, there were no statistically significant differences between groups for any of the outcome measures. Cuff integrity was found in 17 (68 percent) and 20 (90.9 percent) patients in the mini-open and arthroscopic repair groups, respectively; the difference between the groups was not significant.

Warner et al.171 conducted a retrospective cohort study in patients with full-thickness tears. Twenty-one patients were selected (12 received mini-open repair with acromioplasty, nine received all-arthroscopic repair with acromioplasty). All patients were evaluated at a minimum of 2.3 years. The mean followup duration was 4.2 years. Patients were assessed using the SST, pain, range of motion (flexion and external rotation) and strength. Postoperative pain scores for both groups were significantly improved from preoperative measures (p<0.01). A statistically significant improvement in strength (p<0.01) was also observed in the arthroscopic group. Within and between group differences for all remaining outcome measures were not statistically significant.

Youm et al.173 conducted a retrospective cohort study in patients with small, medium, and large tears. Ninety-five patients were selected and 84 evaluated (42 received mini-open repair with acromioplasty, 42 received all-arthroscopic repair with acromioplasty) at a mean of 3.0 years (range: 2 to 5.8 years). Patient function was assessed using the ASES and UCLA scores. At followup, the differences between groups for both scores were not statistically significant.

One CCT and nine cohort studies (two prospective and seven retrospective) provided data for meta-analysis of the effects of mini-open vs. arthroscopic repair on functional outcome measures (Figure 5). Data from the trial and cohort studies was analyzed separately. The following outcome measures were included in the meta-analysis: ASES,154,157,167,173 CMS,119,125 DASH,85 SST171 and the UCLA.114,148 and The mean change between preoperative and postoperative scores was compared for four studies.85,114,119,125,154 The remaining studies provided no baseline data, therefore the endpoint scores are compared between groups.148,157,167,171,173 There were no significant differences between the mini-open and arthroscopic repair groups on functional outcome measures, either for the one CCT or the pooled estimate of nine cohort studies. The CCT favored mini-open repair (MD=0.32; 95% CI, −0.13 to 0.78). The combined estimate of functional outcomes from cohort studies slightly favored arthroscopic repair (SMD=−0.11, 95% CI, −0.28 to 0.06) There was no evidence of heterogeneity between the pooled studies (p=0.67; I2=0 percent).

Two cohort retrospective studies provided data for meta-analysis of the effects of mini-open vs. arthroscopic repair on cuff integrity (Figure 6). The pooled estimate of effect showed no significant difference between the surgical approaches on the proportion of patients with intact RCs, however there was a trend favoring arthroscopic RCR (relative risk=0.80; 95% CI, 0.62 to 1.02). There was no evidence of heterogeneity between the two studies (p=0.44, I2=0 percent).

Open RCR vs. arthroscopic RCR. Three cohort studies (one prospective112 and two retrospective87,134) compared open RCR against arthroscopic RCR. Patient and study characteristics and outcome data are presented in Table 11 and Table 12, respectively.

Table 11 Study and patient characteristics for studies assessing open vs. arthroscopic RCR

Author, year | Intervention (N participants enrolled) Study design | Age (yr), mean±SD (range)/Males, N (%)Other characteristics | Type of tear; Size of tear Duration of symptoms (mo), mean±SD (range)
Costouros JG,87 2006 | G1: Open RCR (19) G2: Arthroscopic RCR (18) Retrospective cohort | G1: 57 yr (40–75)/Males: 14 (74) G2: 54 yr (34–65)/Males: 12 (67) | FTT; NR NR
Ide J,112 2005 | G1: Open RCR (NR) G2: Arthroscopic RCR (NR) Prospective cohort | G1: 57.1 yr (24–72)/Males: 39 (78) Athletes: 2 (4) G2: 57 yr (25–78)/Males: 41 (82) Athletes: 3 (6) | FTT; Sm, Med, Lg, Mass G1: 8 mo (2–24), G2: 6.4 mo (2–36)
Millar NL,134 2009 | G1: Open RCR (49) G2: Arthroscopic knotted RCR (53) G3: Arthroscopic knotless RCR (57) Retrospective cohort | G1: 58 yr (28–87)/Males: 21 (43) G2: 64 yr (40–90)/Males: 24 (45) G3: 69 yr (34–86)/Males: 28 (49) | FTT; Sm, Med, Lg, Mass G1: 15 mo (0.71–81), G2: 7.2 mo (1–39), G3: 6.6 mo (0.5–31)

FTT = full-thickness tear; G = group; Lg = large; Mass = massive; Med = medium; mo = month; NR = not reported; RCR = rotator cuff repair; SD = standard deviation; Sm = small; yr = year

Table 12 Outcome data for studies assessing open vs. arthroscopic RCR

Author, year | Intervention (N analysed) Followup, mean (range) | Outcome | Group 1 Baseline mean±SD (range)/Endpoint mean±SD (range) | Group 2 Baseline mean±SD (range)/Endpoint mean±SD (range) | Group 1 vs. Group 2 p-value
Costouros JG,87 2006 | G1: Open RCR (NR) G2: Arthroscopic RCR (NR) 21.1 mo (12–48) | CMS | 52/70, p=0.02 | 51/75, p<0.001 | NS
Ide J,112 2005 | G1: Open RCR (50) G2: Arthroscopic RCR (50) 4.1 yr (2.1–6.9) | UCLA | 15.5 (7–26)/31.6 (26–35), p<0.0001 | 16.1 (8–24)/32.0 (21–35), p<0.0001 | p>0.05
Ide J,112 2005 | G1: Open RCR (50) G2: Arthroscopic RCR (50) 4.1 yr (2.1–6.9) | JOA^*^ | 56.9 (27–68)/92.1 (67–100), p<0.0001 | 58.7 (32–64)/94.0 (60–100), p<0.0001 | p>0.05
Millar NL,134 2009 | G1: Open RCR (20) G2: Arthroscopic knotted RCR (29) G3: Arthroscopic knotless RCR (38) 2 yr | ASES^†^ 6 mo 2 yr | 43±1 61±2 67±1, p<0.001 | 47±1 74±2 80±2, p<0.001 | G1 vs. G2: p<0.001 G1 vs. G3: p<0.001
Millar NL,134 2009 | G1: Open RCR (20) G2: Arthroscopic knotted RCR (29) G3: Arthroscopic knotless RCR (38) 2 yr | ASES^†^ 6 mo 2 yr | 43±1 61±2 67±1, p<0.001 | G3: 48±1 78±2 79±1, p<0.001 | G1 vs. G2: p<0.001 G1 vs. G3: p<0.001
Millar NL,134 2009 | G1: Open RCR (20) G2: Arthroscopic knotted RCR (29) G3: Arthroscopic knotless RCR (38) 2 yr | OSF^†^ (1–5) 6 mo 2 yr | 2.3±0.1 3.9±0.1 4.4±0.1, p<0.001 | 2.0±0.2 4.2±0.1 4.3±0.1, p<0.001 | G1 vs. G2: NS G1 vs. G3: NS
Millar NL,134 2009 | G1: Open RCR (20) G2: Arthroscopic knotted RCR (29) G3: Arthroscopic knotless RCR (38) 2 yr | OSF^†^ (1–5) 6 mo 2 yr | 2.3±0.1 3.9±0.1 4.4±0.1, p<0.001 | G3: 2.4±0.1 4.1±0.1 4.4±0.1, p<0.001 | G1 vs. G2: NS G1 vs. G3: NS
Millar NL,134 2009 | G1: Open RCR (20) G2: Arthroscopic knotted RCR (29) G3: Arthroscopic knotless RCR (38) 2 yr | RCF Index^†^ 6 mo 2 yr | −16±3 −1±3 −8±4, p<0.001 | −25±3 3±3 −4±2, p<0.001 | G1 vs. G2: NS G1 vs. G3: NS
Millar NL,134 2009 | G1: Open RCR (20) G2: Arthroscopic knotted RCR (29) G3: Arthroscopic knotless RCR (38) 2 yr | RCF Index^†^ 6 mo 2 yr | −16±3 −1±3 −8±4, p<0.001 | G3: −20±3 −1±2 −3±3, p<0.001 | G1 vs. G2: NS G1 vs. G3: NS
Millar NL,134 2009 | G1: Open RCR (20) G2: Arthroscopic knotted RCR (29) G3: Arthroscopic knotless RCR (38) 2 yr | Pain at rest^†^ (0–4) 6 mo 2 yr | 2.4±0.2 1.0±0.1 0.5±0.1, p<0.001 | 2.2±0.1 1.0±0.1 0.6±0.1, p<0.001 | G1 vs. G2: NS G1 vs. G3: NS
Millar NL,134 2009 | G1: Open RCR (20) G2: Arthroscopic knotted RCR (29) G3: Arthroscopic knotless RCR (38) 2 yr | Pain at rest^†^ (0–4) 6 mo 2 yr | 2.4±0.2 1.0±0.1 0.5±0.1, p<0.001 | G3: 1.7±0.2 0.7±0.1 0.6±0.1, p<0.001 | G1 vs. G2: NS G1 vs. G3: NS
Millar NL,134 2009 | G1: Open RCR (20) G2: Arthroscopic knotted RCR (29) G3: Arthroscopic knotless RCR (38) 2 yr | Night Pain^†^ (0–4) 6 mo 2 yr | 2.5±0.2 1.4±0.1 0.9±0.2, p<0.001 | 2.3±0.2 1.0±0.1 0.9±0.1, p<0.001 | G1 vs. G2: NS G1 vs. G3: NS
Millar NL,134 2009 | G1: Open RCR (20) G2: Arthroscopic knotted RCR (29) G3: Arthroscopic knotless RCR (38) 2 yr | Night Pain^†^ (0–4) 6 mo 2 yr | 2.5±0.2 1.4±0.1 0.9±0.2, p<0.001 | G3: 2.2±0.1 0.8±0.1 0.9±0.1, p<0.001 | G1 vs. G2: NS G1 vs. G3: NS
Millar NL,134 2009 | G1: Open RCR (20) G2: Arthroscopic knotted RCR (29) G3: Arthroscopic knotless RCR (38) 2 yr | ROM^†^(degrees) 6 mo 2 yr | ABD: 135±5 154±4 149±5, p<0.01 F: 151±4 163±4 164±4, p<0.01 ER: 53±3 53±2 52±2, NS | ABD: 112±6 159±5 141±5, p<0.001 F: 123±7 163±4 165±4, p<0.001 ER: 47±2 66±3 62±2, p<0.01 | ABD: G1 vs. G2: NS G1 vs. G3: NS F: G1 vs. G2: NS G1 vs. G3: NS ER: G1 vs. G2: p<0.001 G1 vs. G3: p<0.001
Millar NL,134 2009 | G1: Open RCR (20) G2: Arthroscopic knotted RCR (29) G3: Arthroscopic knotless RCR (38) 2 yr | ROM^†^(degrees) 6 mo 2 yr | ABD: 135±5 154±4 149±5, p<0.01 F: 151±4 163±4 164±4, p<0.01 ER: 53±3 53±2 52±2, NS | G3: ABD:133±5.5 163±3.3 152±4, p<0.01 F: 146±5 168±2.5 165±3, p<0.001 ER: 54±2.7 69±2.5 68±3, p<0.001 | ABD: G1 vs. G2: NS G1 vs. G3: NS F: G1 vs. G2: NS G1 vs. G3: NS ER: G1 vs. G2: p<0.001 G1 vs. G3: p<0.001
Millar NL,134 2009 | G1: Open RCR (20) G2: Arthroscopic knotted RCR (29) G3: Arthroscopic knotless RCR (38) 2 yr | Strength^†^ (newton) 6 mo 2 yr | SS: 29±3 50±3 48±3, p<0.001 ER: 39±3 62±4 50±2, p<0.05 Liftoff: 29±2 45±4 57±2, p<0.01 | SS: 23±2 52±3 50±2, p<0.001 ER: 32±2 60±3 52±3, p<0.01 Liftoff: 20±2 38±3 49±4, p<0.001 | SS: G1 vs. G2: NS G1 vs. G3: p<0.05 ER: G1 vs. G2: NS G1 vs. G3: p<0.05 Liftoff: G1 vs. G2: NS G1 vs. G3: NS
Millar NL,134 2009 | G1: Open RCR (20) G2: Arthroscopic knotted RCR (29) G3: Arthroscopic knotless RCR (38) 2 yr | Strength^†^ (newton) 6 mo 2 yr | SS: 29±3 50±3 48±3, p<0.001 ER: 39±3 62±4 50±2, p<0.05 Liftoff: 29±2 45±4 57±2, p<0.01 | G3: SS: 37±3 56±2.8 57±2, p<0.001 ER: 46±2.7 61±2.7 62±3, p<0.001 Liftoff: 29±2.6 40±2.1 50±2, p<0.001 | SS: G1 vs. G2: NS G1 vs. G3: p<0.05 ER: G1 vs. G2: NS G1 vs. G3: p<0.05 Liftoff: G1 vs. G2: NS G1 vs. G3: NS
Millar NL,134 2009 | G1: Open RCR (20) G2: Arthroscopic knotted RCR (29) G3: Arthroscopic knotless RCR (38) 2 yr | Cuff integrity^†^ n/N (%), US | 12/20 (60) | 19/29 (65) | G1 vs. G2: NS G1 vs. G3: NS
Millar NL,134 2009 | G1: Open RCR (20) G2: Arthroscopic knotted RCR (29) G3: Arthroscopic knotless RCR (38) 2 yr | Cuff integrity^†^ n/N (%), US | 12/20 (60) | G3: 31/38 (82) | G1 vs. G2: NS G1 vs. G3: NS

ABD = abduction; ASES = American Shoulder and Elbow Scale; CMS = Constant-Murley score; ER = eternal rotation; G = group; JOA = Japanese Orthopaedic Association scale; mo = month; N = number; NR = not reported; NS = not significant; OSF = Overall Shoulder Function; RCF Index = rotator cuff function index; RCR = rotator cuff repair; ROM = range of motion; SD = standard deviation; SS = supraspinatus; UCLA = University of California Los Angeles Scale; US = ultrasound; yr = year

* Subscores reported

† Values are expressed as mean ± standard error of the mean

A retrospective cohort study was conducted by Costouros et al.87 comparing open vs. arthroscopic repair in patients with full-thickeness tears. Thirty-seven patients were enrolled, of whom 19 received open repair and 18 received arthrosopic repair. Patients were evaluated using the CMS at an average of 21.1 months (range: 12 months to 4 years). Patients in both groups improved significantly from baseline to followup (p=0.02 and p<0.001 in the open and arthroscopic group, respectively), however no differences were seen between treatment groups.

Ide et al.112 conducted a prospective cohort study in patients with small, medium, large, and massive full-thickness tears. One hundred patients were evaluated (50 received open repair with acromioplasty, 50 received all-arthroscopic repair with acromioplasty) at a mean of 4.1 years (range: 2.1 to 6.9 years). Patient function was assessed using UCLA and Japanese Orthopaedic Association (JOA) index scores. At followup, statistically significant differences were observed within both groups for both scores (p<0.0001); however, the differences between the two groups were not statistically significant (p>0.05).

Millar et al.134 conducted a retrospective cohort study evaluating RCR in patients with full-thickness tears of all sizes. A total of 159 patients were enrolled, of which 49 received open repair, 53 received arthroscopic knotted repair, and 57 received arthroscopic knotless repair. Overall, 20, 29 and 38 patients were analyzed at 2 years followup, respectively. Reported outcomes included the ASES, Overall Shoulder Function score, Rotator Cuff Functional Index, pain at rest and at night, range of motion (abduction, flexion, external rotation), strength (supraspinatus, external rotation, liftoff) and cuff integrity. Patients in all three groups showed a significant improvement from baseline to followup. There were significant differences between the open RCR and combined arthroscopic RCR groups for the ASES (p<0.001) and external rotation (p<0.001). In addition, there was a significant difference between open repair and arthroscopic knotless repair for strength in supraspinatus (p<0.05) and external rotation strength (p<0.05). Differences between the two arthroscopic procedures are reported in the operative technique section. There were no significant between-group differences for any of the other outcomes.

Two retrospective87,134 and one prospective112 provided data for meta-analysis of the effects of open vs. arthroscopic repair on functional outcome measures (Table 10). The following outcome measures were included in the meta-analysis: ASES,134 CMS,87 and UCLA.112 The mean change between preoperative and postoperative scores was compared for all of the studies. There were no significant differences between the open and arthroscopic repair groups on functional outcome measures (SMD=−0.49; 95% CI, −1.12 to 0.13). There was significant heterogeneity between the studies (p=0.003; I2=83 percent), where Ide112 showed no difference between the repair approaches and the other two studies favoured arthroscopic RCR. There were no apparent differences between the three studies with regard to the patient age, type of tear, or tear size. Some differences that may have contributed to the varying effect estimates include the prospective direction of Ide et al, and that outcomes were assessed at a longer followup duration compared to the other studies (4.1 years vs. 2 years). It is possible that there may be an initial advantage of arthroscopic repair on functional outcomes, yet that this benefit is not sustained over longer durations of followup.

Table 10 Open vs. arthroscopic RCR on measures of functional outcome

Study or Subgroup | Open RCR | | | Arthroscopic RCR | | | Weight | Std. Mean Difference IV, Random, 95% CI | Std. Mean Difference IV, Random, 95% CI
Study or Subgroup | Mean | SD | Total | Mean | SD | Total | Weight | Std. Mean Difference IV, Random, 95% CI | Std. Mean Difference IV, Random, 95% CI
Cosouros | 18 | 7.05 | 19 | 24 | 7.05 | 18 | 27.8% | −0.83 [−1.51,−0.16]
Ide 2005 | 16.1 | 3.176 | 50 | 15.9 | 2.042 | 50 | 35.5% | 0.07 [−0.32, 0.47]
Millar 2009 | 24 | 7 | 49 | 31.96 | 11.26 | 110 | 36.6% | −0.78 [−1.13,−0.43]
Total (95% CI) | | | 118 | | | 178 | 100.0% | −0.49 [−1.12, 0.13]

Heterogeneity: Tau2 = 0.25; Chi2 = 11.57, df = 2 (P = 0.003); I2 = 83%

Test for overall effect: Z = 1.54 (P = 0.12)

Open or mini-open RCR vs. arthroscopic RCR. Two prospective cohort studies72,77 compared open or mini-open RCR against arthroscopic RCR. These studies are presented as a separate category, since the study outcome data was not reported separately for patients who received open or mini-open repair. Pooled results are shown in Figure 7. Patient and study characteristics and outcome data are presented in Table 13 and Table 14, respectively.

Figure 7 Open or mini-open vs. arthroscopic RCR for pain VAS

Forest plot showing that a meta-analysis was conducted using visual analogue pain data from the two cohort studies. The mean preoperative to postoperative change scores for both treatment arms were compared. The studies both found a statistically significant difference between the groups; in Bishop et al. the open or mini-open group was favored, while in Buess et al. the arthroscopic group was favored. The combined estimate of change in pain scores showed no difference between the interventions (SMD=-0.58; 95% CI, -2.64 to 1.48). There was significant heterogeneity between the studies (p〈0.0001; I2=97 percent).

Table 13 Study and patient characteristics for studies assessing open or mini-open vs. arthroscopic RCR

Author, year | Intervention (N participants enrolled) Study design | Age (yr), mean±SD (range)/Males, N (%) Other characteristics | Type of tear; Size of tear Duration of symptoms (mo), mean±SD (range)
Bishop J,72 2006 | G1: Open or mini-open RCR (47) G2: Arthroscopic RCR (55) Prospective cohort | G1: 64 yr/NR G2: 64 yr/NR | FTT; Sm, Lg, Mass NR
Buess E,77 2005 | G1: Open or mini-open RCR (32 shoulders) G2: Arthroscopic RCR (67 shoulders) Prospective cohort | G1: 48.3 yr (18–73)/Males: 21 (72) Manual laborers: 13 (45) G2: 53.2 yr (20–77)/Males: 44 (70) Manual laborers: 30 (48) | NR; Sm, Med, Lg, Mass NR

FTT = full-thickness tear; G = group; Lg = large; Mass = massive; Med = medium; N = number; NR = not reported; RCR = rotator cuff repair; SD = standard deviation; Sm = small; yr = year

Table 14 Outcome data for studies assessing open or mini-open vs. arthroscopic RCR

Author, year | Intervention (N analysed) Followup, mean (range) | Outcome | Group 1 Baseline mean±SD (range)/Endpoint mean±SD (range) | Group 2 Baseline mean±SD (range)/Endpoint mean±SD (range) | Group 1 vs. Group 2 p-value
Bishop J,72 2006 | G1: Open or mini-open RCR (32) G2: Arthroscopic RCR (40) 12 mo | ASES | 40/85, p<0.0001 | 46/84, p<0.0001 | p=0.73
Bishop J,72 2006 | G1: Open or mini-open RCR (32) G2: Arthroscopic RCR (40) 12 mo | CMS | 53/80, p<0.0001 | 52/75, p<0.0001 | p=0.13
Bishop J,72 2006 | G1: Open or mini-open RCR (32) G2: Arthroscopic RCR (40) 12 mo | Pain (VAS) | 8.2/1.1, p<0.0001 | 5.2/1.5, p<0.0001 | p=0.41
Bishop J,72 2006 | G1: Open or mini-open RCR (32) G2: Arthroscopic RCR (40) 12 mo | ROM (lb) | F: 6.2/12.8, p<0.005 ER: 10/18, p<0.01 | F: 5.8/10.4, p<0.01 ER: 9.5/13.6, p<0.01 | F: p=0.220 ER: p≤0.05
Bishop J,72 2006 | G1: Open or mini-open RCR (32) G2: Arthroscopic RCR (40) 12 mo | Cuff integrity n/N (%), MRI | 22/32 (69) | 21/40 (53) | p=0.23^*^
Buess E,77 2005 | G1: Open or mini-open RCR (29) G2: Arthroscopic RCR (63) 2 yr (15 mo–3.3 yr) | SST | NR/8.7 | NR/9.7 | p=0.33
Buess E,77 2005 | G1: Open or mini-open RCR (29) G2: Arthroscopic RCR (63) 2 yr (15 mo–3.3 yr) | Pain (VAS) | 7.8 (4.5–10)/NR | 8.0 (2.5–10)/NR | p=0.02
Buess E,77 2005 | G1: Open or mini-open RCR (29) G2: Arthroscopic RCR (63) 2 yr (15 mo–3.3 yr) | Days until pain free, mean (range) | 95.6 (7–360) | 94.4 (2–375) | NR

ASES = American Shoulder and Elbow Scale; CMS = Constant-Murley score; ER = external rotation; F = flexion; G = group; lb = pound; mo = month; MRI = magnetic resonance imaging; N = number; NR = not reported; RCR = rotator cuff repair; ROM = range of motion; SD = standard deviation; SST = simple shoulder test; VAS = visual analogue scale; yr = year

* Calculated by UAEPC

Bishop et al.72 conducted a prospective cohort study in patients with small, large, and massive full-thickness tears. One hundred and two patients were selected and 72 evaluated (32 received open repair [24 patients] or mini-open repair [8 patients] and 40 received arthroscopic repair) at 1 year. Patient function was assessed using the ASES score, CMS, pain, and range of motion (forward elevation and external rotation). Within group differences for all measures were statistically significant. All between group differences were not significant with the exception of an improvement in external rotation, which was significantly greater for the open and mini-open group (p≤0.05). Cuff integrity was evaluated using MRI at 12 months; 22 patients (69 percent) and 21 patients (52.5 percent) had intact cuffs in the open or mini-open vs. arthroscopic group, respectively. The difference between groups was not significant.

Buess et al.77 conducted a prospective cohort study in patients with all tear sizes. Ninety-six patients (99 shoulders) were selected and 92 evaluated (29 received open or mini-open repair and 63 received arthroscopic repair) at a mean followup of 2 years (range: 15 months to 3.3 years). Patients were evaluated on the SST, a visual analogue scale for pain, and number of days until pain free. The arthroscopic group had significantly better pain relief on the visual analogue scale than the open/mini-open group at final followup (p=0.02). Postoperative SST scores were not statistically significant between the groups (p=0.33). Both groups showed similar duration in the mean number of days until pain free (95.6 for the open and mini-open group, 94.4 for the arthroscopic group).

A meta-analysis was conducted using visual analogue pain data from the two cohort studies (Figure 7).72,77 The mean preoperative to postoperative change scores for both treatment arms were compared. The studies both found a statistically significant difference between the groups; in Bishop et al.72 the open or mini-open group was favored, while in Buess et al.77 the arthroscopic group was favored. The combined estimate of change in pain scores showed no difference between the interventions (SMD=−0.58; 95% CI, −2.64 to 1.48). There was significant heterogeneity between the studies (p<0.0001; I2=97 percent). The heterogeneity may be attributable, in part, to differences between the study populations. Buess et al.77 included younger patients, of which a large proportion were manual laborers (nearly 50 percent), while the population in Bishop et al.72 was significantly older.

Open RCR vs. open or arthroscopic debridement. Four studies (two CCTs,137,143 and two cohort studies139,165) compared open RCR vs. arthroscopic debridement. Pooled results are shown in Figure 8. Patient and study characteristics and outcome data are presented in Table 15 and Table 16, respectively.

Figure 8 Open RCR vs. open or arthroscopic debridement for measures of functional outcome

Forest plot showing that two CCTs and two cohort studies provided data for meta-analysis of the effects of open repair versus arthroscopic debridement on functional outcome measures. Data from the trials and cohort studies was analyzed separately. The following measures were included in the meta-analysis: CMS, UCLA score, and the Insalata shoulder rating scale. The preoperative to postoperative change score was compared between groups for Vad et al. and Montgomery et al; the remaining studies did not report baseline data, therefore the postoperative scores were compared between groups. The combined estimate of changes in measures of functional outcomes indicated a significant improvement in favor of open RCR for both the trials (SMD=0.59; 95% CI, 0.15 to 1.03) and the cohort studies (SMD=1.00; 95% CI, 0.11 to 1.90). There was no evidence of heterogeneity for the trials (p=0.22; I2=32 percent), however there was substantial heterogeneity for the cohort studies (p=0.03; I2=79 percent).

Table 15 Study and patient characteristics for studies assessing open RCR vs. arthroscopic debridement

Author, year | Intervention (N participants enrolled) Study design | Age (yr), mean±SD (range)/Males, N (%) Other characteristics | Type of tear; Size of tear Duration of symptoms (mo), mean±SD (range)
Montgomery TJ,137 1994 | G1: Open RCR (58 shoulders) G2: Arthroscopic debridement (49 shoulders) CCT | G1: 58±11.6 yr (32–79)/NR G2: 60±12.2 yr (36–79)/NR | FTT; Sm, Med, Lg, Mass NR
Motycka T,139 2004 | G1: Open RCR (NR) G2: Open or arthroscopic debridement (NR) Retrospective cohort | G1: NR/NR G2: NR/NR | NR; Lg, Mass NR
Ogilvie-Harris DJ,143 1993 | G1: Open RCR (25) G2: Arthroscopic debridement (25) CCT | G1: NR/NR G2: NR/NR | NR; Sm, Med, Lg NR
Vad VB,165 2002 | G3^*^: Open RCR (36) G4: Arthroscopic debridement (32) Retrospective cohort | G3: 59.4 yr/NR G4: 62.9 yr/NR | FTT; Mass 6.3 mo (1–17)

CCT = controlled clinical trial; FTT = full-thickness tear; G = group; Lg = large; Mass = massive; Med = medium; NR = not reported; RCR = rotator cuff repair; SD = standard deviation; Sm = small

* Groups 1 and 2 are nonoperative interventions

Table 16 Outcome data for studies assessing open RCR vs. arthroscopic debridement

Author, year | Intervention (N analysed) Followup, mean (range) | Outcome | Group 1 Baseline mean±SD (range)/Endpoint mean±SD (range) | Group 2 Baseline mean±SD (range)/Endpoint mean±SD (range) | Group 1 vs. Group 2 p-value
Montgomery TJ,137 1994 | G1: Open RCR (50 shoulders) G2: Arthroscopic debridement (38 shoulders) 2–5 yr | UCLA^*^ | 11/30.5 | 13/25.1 | p=0.0028
Motycka T,139 2004 | G1: Open RCR (33) G2: Open or arthroscopic debridement (31) 5.7 yr (2.1–14.2) | CMS^*^ | NR/76 (16–100) | NR/65.1 (10–98) | p=0.73
Ogilvie-Harris DJ,143 1993 | G1: Open RCR (23) G2: Arthroscopic debridement (22) 2–5 yr | UCLA^*^ | NR/29.1 | NR/26.9 | p=0.017
Vad VB,165 2002 | G3^†^: Open RCR (36) G4: Arthroscopic debridement (32) 3.2 yr (2–7) | Insalata^*^ | 33±1.2/83.6±1.4, p≤0.05 | 42.3±1.4/81.4±1.3, p≤0.05 | p≤0.01^‡^
Vad VB,165 2002 | G3^†^: Open RCR (36) G4: Arthroscopic debridement (32) 3.2 yr (2–7) | ROM (degrees) | ABD: 72/116, p≤0.05 | ABD: 74/110, p≤0.05 | NR
Vad VB,165 2002 | G3^†^: Open RCR (36) G4: Arthroscopic debridement (32) 3.2 yr (2–7) | Time to maximal ROM, mean (range) | 6.8 mo (4–16) | 3.2 mo (1–8) | NR

ABD = abduction; CMS = Constant-Murley score; G = group; Insalata = Insalata Shoulder Rating Questionnaire; NR = not reported; RCR = rotator cuff repair; ROM = range of motion; SD = standard deviation; UCLA = University of California Los Angeles Scale; yr = year

* Subscores reported

† Groups 1 and 2 are nonoperative interventions

‡ Calculated by UAEPC

Montgomery et al.137 conducted a CCT comparing open RCR vs. arthroscopic debridement. All patients had full-thickness tears; tear size ranged from small to massive. One hundred and six patients (107 shoulders) were randomly assigned to the interventions (58 to open repair and acromioplasty, 49 to arthroscopic debridement and subacromial decompression) and 87 patients (88 shoulders) were included in final analysis. Followup evaluations were conducted 2 to 5 years postoperatively. The UCLA shoulder scale was used to evaluate patient function. There was improvement from the preoperative to postoperative scores in both groups. At final evaluation, there was a significant difference between two groups (p=0.0028), in favor of the open RCR group.

Motycka et al.139 conducted a retrospective cohort study comparing open RCR vs. open or arthroscopic debridement in patients with large and massive tears. Overall, 76 patients were enrolled in the study; of these, 64 were included in the final analyses (33 received open repair with acromioplasty, 31 received open debridement with acromioplasty [15] or all-arthroscopic debridement and acromioplasty [16]). The mean length of followup was 5.7 years (range: 2.1 to 14.2). Patients were evaluated using the CMS. There was no statistically difference between the endpoint scores of the two groups (p=0.73).

Ogilvie-Harris et al.143 conducted a CCT comparing open RCR vs. arthroscopic debridement in patients with RC tears 1 to 4 cm in size. Fifty patients were assigned to the interventions (25 patients received open repair with acromioplasty, 25 received all-arthroscopic debridement with acromioplasty); 45 were included in the final analyses. Followup duration ranged from 2 to 5 years. Patient function was evaluated using the UCLA scale. Both groups showed a significant improvement in UCLA subscores (pain, function, active forward flexion, and strength of forward flexion) from preoperative to postoperative measures. The difference between the postoperative scores of the two groups was statistically significant (p=0.017), favoring the open RCR group.

Vad et al.165 conducted a retrospective cohort study comparing open RCR vs. arthroscopic debridement in patients with massive full-thickness tears. Sixty-eight patients were enrolled in the two operative arms (36 received open repair, 32 received all-arthroscopic debridement). All patients were followed up for at least 2 years; mean follow up duration was 3.2 years (range: 2 to 7). Patients were evaluated using the Insalata shoulder rating scale, range of motion (abduction), and time to maximal range of motion. For both groups, there were statistically significant improvement between the preoperative and postoperative scores for the Insalata rating and range of motion (p<0.05). The Insalata scores at final followup were significantly different between groups, favoring open repair. The time to maximal range of motion differed between the groups, with 6.8 months for the open RCR group and 3.2 months in the arthroscopic debridement group.

Two CCTs137,139 and two cohort studies143,165 provided data for meta-analysis of the effects of open repair vs. arthroscopic debridement on functional outcome measures (Figure 8). Data from the trials and cohort studies was analyzed separately. The following measures were included in the meta-analysis: CMS,139 UCLA score,137,143 and the Insalata shoulder rating scale.165 The preoperative to postoperative change score was compared between groups for Vad et al.165 and Montgomery et al;137 the remaining studies did not report baseline data, therefore the postoperative scores were compared between groups. The combined estimate of changes in measures of functional outcomes indicated a significant improvement in favor of open RCR for both the trials (SMD=0.59; 95% CI, 0.15 to 1.03) and the cohort studies (SMD=1.00; 95% CI, 0.11 to 1.90). There was no evidence of heterogeneity for the trials (p=0.22; I2=32 percent), however there was substantial heterogeneity for the cohort studies (p=0.03; I2=79 percent).

Arthroscopic RCR vs. acromioplasty. Two RCTs102,133 compared arthroscopic RCR vs. arthroscopic RCR with acromioplasty, while one prospective cohort study compared arthrosopic RCR vs. acromioplasty alone.140 Pooled results are shown in Figure 9. Patient and study characteristics and outcome data are presented in Table 17 and Table 18, respectively.

Figure 9 Arthroscopic RCR with acromioplasty vs. RCR without acromioplasty for measures of functional outcome

Forest plot showing that two RCTs provided data for meta-analysis of the effects of arthroscopic repair with acromioplasty versus without acromioplasty on functional outcomes. Outcome measures used in the analysis include the ASES index and the CMS. The difference between endpoint scores was analyzed in both studies.

Table 17 Study and patient characteristics for studies assessing arthroscopic RCR vs. acromioplasty

Author, year | Intervention (N participants enrolled) Study design | Age (yr), mean±SD (range)/Males, N (%) Other characteristics | Type of tear; Size of tear Duration of symptoms (mo), mean±SD (range)
Gartsman GM,102 2004 | G1: Arthroscopic RCR & acromioplasty (47) G2: Arthroscopic RCR (46) RCT | G1: 59.3 yr (39–81)/Males: 27 (57) G2: 60 yr (37–79)/Males: 24 (52) | FTT; G1: 2.1 cm, G2: 2.3 cm NR
Milano G,133 2007 | G1: Arthroscopic RCR & acromioplasty (40) G2: Arthroscopic RCR (40) RCT | G1: 61±7 yr/Males: 20 (50) G2: 59.7±9.7 yr/Males: 19 (48) | FTT; NR NR
Mullett H,140 2006 | G1: Arthroscopic acromioplasty (114) G2: Arthroscopic RCR (96) Prospective cohort | G1: NR/Males: NR G2: NR/Males: NR | NR; Sm, Med NR

cm = centimetre; FTT = full-thickness tear; G = group; Med = medium; mo = month; N = number; NR = not reported; RCR = rotator cuff repair; RCT = randomized controlled trial; SD = standard deviation; Sm = small; yr = year

Table 18 Outcome data for studies assessing arthroscopic RCR vs. acromioplasty

Author, year | Intervention (N analysed) Followup, mean (range) | Outcome | Group 1 Baseline mean±SD (range)/Endpoint mean±SD (range) | Group 2 Baseline mean±SD (range)/Endpoint mean±SD (range) | Group 1 vs. Group 2 p-value
Gartsman GM,102 2004 | G1: Arthroscopic RCR & acromioplasty (47) G2: Arthroscopic RCR (46) 15±3.3 mo (NR) | ASES | 31.1 (20–46.7)/91.5±10.3 | 31 (18.3–41.7)/89.2±15.1 | p=0.39
Milano G,133 2007 | G1: Arthroscopic RCR & acromioplasty (37) G2: Arthroscopic RCR (34) 2 yr | CMS | NR/103.6 | NR/96.1 | NR
Milano G,133 2007 | G1: Arthroscopic RCR & acromioplasty (37) G2: Arthroscopic RCR (34) 2 yr | DASH | NR/18.2 | NR/23.1 | NR
Milano G,133 2007 | G1: Arthroscopic RCR & acromioplasty (37) G2: Arthroscopic RCR (34) 2 yr | Work-DASH | NR/23.7 | NR/26.2 | NR
Mullett H,140 2006 | G1: Arthroscopic acromioplasty (NR) G2: Arthroscopic RCR (NR) 3 yr | CMS | NR/69.8 | NR/86.4 | NR

ASES = American Shoulder and Elbow Surgeon scale; CMS = Constant-Murley score; DASH = Disabilities of the Arm, Shoulder and Hand scale; G = group; mo = month; N = number; NR = not reported; RCR = rotator cuff repair; SD = standard deviation; yr = year

Gartsman et al.102 conducted a RCT in patients with full-thickness tears limited to the supraspinatus tendon. Ninety-three patients were randomized (47 received all-arthroscopic repair with acromioplasty, 46 received all-arthroscopic repair with no additional procedures). All patients were followed up for at least 1 year; the mean followup duration was 15.6±3.3 months. In the group treated with arthroscopic RCR and acromioplasty, the mean tear size was 2.1 cm; in the group treated with arthroscopic RCR alone, the mean tear size was 2.3 cm. The ASES index was used to evaluate patient function. There was no statistical difference in the postoperative endpoint scores between the two groups (p=0.39).

Milano et al.133 conducted a RCT in patients with full-thickness tears. Overall, 80 patients were randomly assigned to the interventions (40 received arthroscopic repair and acromioplasty, 40 received arthroscopic repair without acromioplasty); 71 were included in the final analyses. Followup duration was 2 years. Patients were evaluated using the CMS, the Disabilities of the Arm, Shoulder and Hand (DASH) score, and the Work-DASH score. Endpoint scores were comparable between the groups, with the arthroscopic group with acromioplasty scoring slightly higher on the postoperative CMS, and the group without acromioplasty scoring somewhat higher on the DASH and Work-DASH. Baseline and p-values for between and within-group differences were not reported.

Mullett et al.140 compared arthroscopic RCR vs. acromioplasty without repair in a prospective cohort study. A total of 210 patients with small and medium sized tears were enrolled (114 received acromioplasty/subacromial decompression without repair, 96 received arthroscopic RCR). Patients were evaluated at 3 years followup using the CMS. The arthoscopic repair group had a higher postoperative score (86.4) compared with the acromioplasty group (69.8), however baseline values and the significance of the difference between groups were not reported.

Two RCTs102,133 provided data for meta-analysis of the effects of arthroscopic repair with acromioplasty vs. without acromioplasty on functional outcomes (Figure 9). Outcome measures used in the analysis include the ASES index102 and the CMS.133 The difference between endpoint scores was analyzed in both studies.

Other operative approaches. There were seven studies (two RCTs,96,97 one CCT,163 and four retrospective cohort studies63,75,94,138) that could not be classified into one of the above categories. The intervention comparisons examined in these studies included: biceps tenotomy vs. tenodesis,75 RCR vs. palliative treatment (partial repair and biceps tenotomy),94 arthroscopic repair with SLAP repair vs. arthroscopic repair with biceps tenotomy,96 arthroscopic RCR plus tenodesis with proximal biceps detachment vs. without proximal biceps detachment,97 arthroscopic debridement with biceps tenotomy vs. without biceps tenotomy,63 complete RCR vs. partial RCR vs. debridement,138 and classical vs. modified open acromioplasty.163 None of the studies could be pooled in a meta-analysis, as each study examined a different treatment comparison. Patient and study characteristics and outcome data are presented in Table 19 and Table 20, respectively.

Table 19 Study and patient characteristics for studies assessing other operative approaches

Author, year | Intervention (N participants enrolled) Study design | Age (yr), mean±SD (range)/Males, N (%) Other characteristics | Type of tear; Size of tear Duration of symptoms (mo), mean±SD (range)
Boileau P,75 2007 | G1: Biceps tenotomy (NR) G2: Biceps tenodesis (NR) Retrospective cohort | Total: 68 yr (52–85)/Males: 26 (38) | FTT; Mass NR
Favard L,94 2009 | G1: Watertight anatomical RCR (103) G2: Palliative treatment (89) Retrospective cohort | G1: 55.2±6.2 yr/Males: NR G2: 57.1±5.5 yr/Males: NR | FTT; Mass NR
Franceschi F,96 2008 | G1: Arthroscopic RCR & SLAP repair (31) G2: Arthroscopic RCR & biceps tenotomy (32) RCT | G1: 61.8 yr (51–79)/Males: 18 (58) G2: 64.7 yr (53–81)/Males: 15 (47) | NR; Sm, Med, Lg 21 mo
Franceschi F,97 2007 | G1: Tenodesis without detachment (11) G2: Tenodesis with detachment (tenotomy) (11) RCT | G1: 60.3±12.4 yr (41–79)/Males: 6 (55) Manual laborers: 3 (27) G2: 58.1±14.5 yr (40–81)/Males: 5 (46) Manual laborers: 3 (27) | FTT; Mass NR
Klinger HM,63 2005 | G1: Arthroscopic debridement (24) G2: Arthroscopic debridement & biceps tenotomy (17) Retrospective cohort | G1: 66 yr (61–79)/Males: 15 (63) G2: 68 (63–82)/Males: 10 (59) | FTT; Mass G1: 11 mo (6–23), G2:10 mo (6–18)
Moser M,138 2007 | G1: Complete RCR (21) G2: Partial RCR (11) G3: Debridement (6) Retrospective cohort | Total: 62.5 yr (33–81)/Males: 28 (74) | NR; Mass NR
Torrens C,163 2003 | G1: Classical open acromioplasty (20) G2: Modified open acromioplasty (22) CCT | G1: 55.9 yr/Males: 4 (20) G2: 63.8 yr/Males: 4 (18) | NR; Sm, Med, Lg, Mass NR

CCT = controlled clinical trial; FTT = full-thickness tear; G = group; Lg = large; Med = medium; Mass = massive; NR = not reported; RCR = rotator cuff repair; RCT = randomized controlled trial; SD = standard deviation; Sm = small; yr = year

Table 20 Outcome data for studies assessing other approaches

Author, year | Intervention (N analysed) Followup, mean (range) | Outcome | Group 1 Baseline mean±SD (range)/Endpoint mean±SD (range) | Group 2 Baseline mean±SD (range)/Endpoint mean±SD (range) | Group 1 vs. Group 2 p-value
Boileau P,75 2007 | G1: Biceps tenotomy (39 shoulders) G2: Biceps tenodesis (33 shoulders) 2.9±0.6 yr (2–6.3) | CMS | NR/61.2±18 | NR/72.8±12 | p>0.05
Boileau P,75 2007 | G1: Biceps tenotomy (39 shoulders) G2: Biceps tenodesis (33 shoulders) 2.9±0.6 yr (2–6.3) | ROM | F (active): NR/146.2±34.8 F (passive): NR/166.4±21.3 ER (active): NR/32.2±22.0 ER (passive): NR/51.3±16.8 IR: NR/L3 | F (active): NR/164.2±27.6 F (passive): NR/173±10.5 ER (active): NR/40.5±20.9 ER (passive): NR/52.3±16.9 IR: NR/L3 | p>0.05
Favard L,94 2009 | G1: Watertight anatomical repair (NR) G2: Palliative (NR) G1: 50.1±27 G2: 74.4±36.6 | CMS | 37.7±17.1/70±15.2, p<0.01 | 40.6±13.3/64±16.6, p<0.01 | p<0.05
Franceschi F,96 2008 | G1: Arthroscopic RCR + SLAP repair (31) G2: Arthroscopic RCR + biceps tenotomy (32) 5.2 yr (2.9–7.8) | UCLA^*^ | 10.4 (6–14)/27.9 (24–35), p<0.001 | 10.1 (5–14)/32.1 (30–35), p<0.001 | p≤0.05
Franceschi F,96 2008 | G1: Arthroscopic RCR + SLAP repair (31) G2: Arthroscopic RCR + biceps tenotomy (32) 5.2 yr (2.9–7.8) | ROM (degrees) | F: 107 (30–140)/139 (120–170), p<0.001 ER: 81.7 (65–95)/121.4 (90–140), p<0.001 IR: 26.0 (20–33)/34.4 (26–40), p<0.001 | F: 99 (30–140)/166 (140–170), p<0.001 ER: 76.6 (60–90)/134.3 (90–140), p<0.001 IR: 29.1 (21–35)/40.0 (30–45), p<0.001 | p≤0.05
Franceschi F,97 2007 | G1: Tenodesis without detachment (11) G2: Tenodesis with detachment (tenotomy) (11) 3.9 yr (3–4.9) | UCLA | 10.5 (5–15)/33 (29–35), p≤0.05 | 11.1/32.9, p≤0.05 | p>0.05
Franceschi F,97 2007 | G1: Tenodesis without detachment (11) G2: Tenodesis with detachment (tenotomy) (11) 3.9 yr (3–4.9) | ROM (degrees) | F: 102 (30–140)/161 (150–170), p≤0.05 ER: 37 (30–60)/59 (45–70), p≤0.05 IR^†^: L5 - T10/T11 - T5 | F: 110 (30–150)/159 (140–170), p≤0.05 ER: 41 (30–60)/60 (45–90), p≤0.05 IR^†^: L5 - T12/T12 - T5 | p>0.05
Klinger HM,63 2005 | G1: Arthroscopic debridement (24) G2: Arthroscopic debridement + biceps tenotomy (17) 2.6 yr (2–4) | CMS | 39 (19–54)/67 (41–87) | 41 (16–60)/69 (49–87) | p>0.05
Moser M,138 2007 | G1: Complete RCR (NR) G2: Partial repair (NR) G3: Debridement (NR) 2 yr (minimum) | SPADI^*^ | NR/17.9 | NR/29.5 | p=0.235
Moser M,138 2007 | G1: Complete RCR (NR) G2: Partial repair (NR) G3: Debridement (NR) 2 yr (minimum) | SPADI^*^ | NR/17.9 | G3: NR/38.4 | p=0.235
Moser M,138 2007 | G1: Complete RCR (NR) G2: Partial repair (NR) G3: Debridement (NR) 2 yr (minimum) | ROM (degrees) | Protraction: NR/124.5 ER: NR/45.6 IR: NR/T9 | Protraction: NR/120 ER: NR/27 IR: NR/T11 G3: Protraction: NR/110.8 ER: NR/41.6 IR: NR/T5 | Protraction: p=0.78 ER: p=0.029 IR: p=0.08
Moser M,138 2007 | G1: Complete RCR (NR) G2: Partial repair (NR) G3: Debridement (NR) 2 yr (minimum) | Strength | Protraction: NR/16.1 Nm, 11.9 (ft-lbs) ER: NR/19.3 Nm, 14.2 (ft-lbs) | Protraction: NR/16.8 Nm, 12.4 (ft-lbs) ER: NR/16.9 Nm, 12.5 (ft-lbs) G3: Protraction: NR/12.9 Nm, 9.5 (ft-lbs) ER: NR/10.03 Nm, 7.4 (ft-lbs) | Protraction: p=0.48 ER: p=0.08
Torrens C,163 2003 | G1: Classical open anterior acromioplasty (20) G2: Modified open anterior acromioplasty (22) 18 mo (NR) | CMS | 46.7/74 | 53.3/80 | NR

ASES = American Shoulder and Elbow Scale; CMS = Constant-Murley score; DASH = Disabilities of the Arm, Shoulder and Hand; ER = external rotation; F = flexion; IR = internal rotation; ft-lbs = foot pounds; G = group; Nm = nanometer; NR = not reported; RCR = rotator cuff repair; ROM = range of motion; SD = standard deviation; SLAP = superior labral tear from anterior to posterior; SPADI = Shoulder Pain and Disability Index; UCLA = University of California Los Angeles Scale; yr = year

* Subscores reported

† vertebral level

Boileau et al.75 conducted a retrospective cohort study in patients with massive irreparable tears. Overall, 78 patients (82 shoulders) were enrolled in the study; of these, 68 patients (72 shoulders) were included in analyses (39 shoulders received biceps tenotomy, 33 shoulders received biceps tenodesis). The mean length of followup was 2.9±0.6 years(range: 2 to 6.3 years). Patients were evaluated using the CMS and active and passive range of motion (flexion, external and internal rotation). Together, the groups showed significant improvement in the CMS and active flexion from preoperative to postoperative measures (p<0.001), however the mean change from baseline to endpoint was not reported separately by group. There was no statistically significant between-group differences at endpoint scores.

Favard et al.94 conducted a retrospecitve cohort study comparing watertight anatomical repair vs. palliative treatment in a sample of patients younger than 65 years with a massive RC tear. A total of 192 patients were enrolled; 103 received RCR, while 89 received palliative treatment, including tenotomy of the long head of biceps (n=48) or partial repair (n=41). Patients were evaluated using the CMS at an average of 4.1 years and 6.2 years for the repair and palliative treatment groups, respectively. A significant difference was observed between baseline and endpoint scores in both groups. In addition, there was a significant difference between the groups (p<0.05), in favour of the anatomical repair group.

Franceschi et al.96 conducted a RCT in patients with RC tears limited to supraspinatus and infraspinatus tendon; tear size ranged from small to large. Sixty-three patients were randomly assigned to the interventions (31 received arthroscopic repair with SLAP repair, 32 received arthroscopic repair with biceps tenotomy) and evaluated at a mean length of followup of 5.2 years (range: 2.9 to 7.8 years). Patients were assessed using the UCLA shoulder scale and range of motion (flexion, external and internal rotation). For both groups, there was significant improvement in total UCLA scores and range of motion from preoperative to postoperative scores (p<0.001). Moreover, there was a significant difference in total postoperative UCLA scores and range of motion between the two groups, in favour of the arthroscopic RCR with biceps tenotomy group (p≤0.05).

Franceschi et al.97 conducted a RCT in patients with massive full-thickness tears. Twenty-two patients were randomly assigned to the interventions (11 to tenodesis without detachment, 11 to tenodesis with detachment) and followed for a mean of 3.9 years (range: 3 to 4.9 years). All patients were evaluated using the UCLA shoulder scale and range of motion (flexion, external and internal rotation). For both groups, there was significant improvement in total UCLA scores and range of motion from preoperative to postoperative scores (p≤0.05). However, neither the difference between the groups in total postoperative UCLA scores nor in range of motion was statistically significant (p>0.05).

Klinger et al.63 conducted a retrospective cohort study in patients with massive irreparable tears. Forty-one patients were enrolled in the study (24 received arthroscopic debridement and acromioplasty, 17 received arthroscopic debridement, acromioplasty and biceps tenotomy). All patients were followed up for at least 2 years; mean followup was 2.6 years (range: 2 to 4 years). All patients were assessed using the CMS. There was no statistically significantly difference between the groups in the endpoint score (p>0.05).

Moser et al.138 conducted a retrospective cohort study in patients with massive full-thickness tears. Thirty-eight patients were enrolled in the study (21 received open repair, 11 received partial open repair, 6 received debridement). All patients were evaluated using the Shoulder Pain and Disability Index (SPADI) score, range of motion (protraction, external and internal rotation) and strength (protraction, external rotation), and for at least 2 years. There were no significant endpoint differences between the groups on any outcome, with the exception of external rotation range of motion (p=0.029), which favored complete RCR.

Torrens et al.163 conducted a CCT in patients with small to massive tears. Forty-two patients were enrolled in the study (20 received open repair with classic open acromioplasty, 22 received open repair with modified acromioplasty). All patients were followed up for at least 1 year; the mean followup was 18 months. The CMS was used to evaluate patient function. For both groups, the CMS improved from baseline to endpoint.

#### Operative Approach—Uncontrolled Studies

Fifty-eight uncontrolled studies (43 BA,60,65,69,70,74,76,79,80,82–84,89–91,95,100,101,103,104,108,110,111,115,116,120–124,127,130,131,142,145,151,153,156,158,160,161,166,168,169 9 prospective cohorts with BA data,62,86,92,93,107,126,141,144,146 5 retrospective cohorts with BA data128,135,149,150,162 and one case-control study with BA data164) assessed the effectiveness of operative approaches in the RC tear population. The studies were published from 1993 to 2009 (median=2005; IQR: 2002 to 2007).

Open RCR. Fourteen uncontrolled studies (10 BA,60,79,83,103,108,115,131,145,151,153 one prospective cohorts with BA data,86 two retrospective cohorts with BA data,128,135 and one case-control study with BA data164) evaluated the effectiveness of open RCR. The studies were published from 1993 to 2007, with 2001 the median year of publication (IQR: 1995 to 2005).

The number of participants enrolled in the studies ranged from 25 to 224 (median=57; IQR: 43 to 97). The median followup duration was 2.2 years (IQR: 18 months to 4 years). The mean age of the participants ranged from 41 to 65 years. Of the 10 studies that reported type of tear, eight studies included only patients with full-thickness tears (80 percent) and two studies108,164 examined patients with partial- or full-thickness tears (20 percent). All tear sizes were included in six studies, 79,83,115,135,145,151 small to large tears were included in two studies,60,86 medium to massive164 and large to massive153 in one study each. The tear size was not clearly described in four studies. 103,108,128,131 Recreational athletes were included in three studies,60,83,135 and smokers in one study.128 One study reported the proportion of patients in jobs with strenuous manual labour135 and three studies included patients with a workers’ compensation board (WCB) claim.60,135,164

Health-related quality of life was reported in one study,131 while 10 studies used a functional outcome measure. 60,79,86,103,108,128,131,135,151,153 Three studies reported either the time until patients returned to work,60 or the proportion of patients that returned to work.83,135 Cuff integrity was reported in one study.103

The figures below present the preoperative and postoperative functional scores over time for the BA studies (Figure 10), cohort studies (Figure 11), and trials (Figure 12) that examine open RCR. For one uncontrolled study, data from a 10-year followup publication61 was incorporated into the initial publication.60 The shape of the markers indicates the outcome scale used in the study, while the size is proportionate to the square root of the study sample size. Regardless of the outcome measure used and the study design (trial, cohort or uncontrolled study), the studies all indicate improvement in functional score from baseline to final followup.

Figure 10 Uncontrolled examining functional outcomes for open RCR

The figure presents the preoperative and postoperative functional scores over time for the BA studies that examine open RCR. For one uncontrolled study, data from a 10-year followup publication was incorporated into the initial publication. Regardless of the outcome measure used and the study design (trial, cohort or uncontrolled study), the studies all indicate improvement in functional score from baseline to final followup.

Figure 11 Cohort studies examining functional outcomes for open RCR

The figure presents the preoperative and postoperative functional scores over time for the cohort studies that examine open RCR. For one uncontrolled study, data from a 10-year followup publication was incorporated into the initial publication. Regardless of the outcome measure used and the study design (trial, cohort or uncontrolled study), the studies all indicate improvement in functional score from baseline to final followup.

Figure 12 Trials examining functional outcomes for open RCR

The figure presents the preoperative and postoperative functional scores over time for the trials that examine open RCR. For one uncontrolled study, data from a 10-year followup publication was incorporated into the initial publication. Regardless of the outcome measure used and the study design (trial, cohort or uncontrolled study), the studies all indicate improvement in functional score from baseline to final followup.

Mini-open RCR. Two BA studies69,76 examined the effectiveness of mini-open RCR. The studies were published in 2004^76^ and 2005.^69^ The number of enrolled participants was 84 in both studies. The mean followup was 12 mo.69 and 35 mo.76 The mean ages were 53^69^ and 54 years.76 One study69 included full-thickness tears of all sizes and participants with WCB claims (n=20, 24 percent), while tear characteristics were not reported in the other study.76

The reported outcomes included functional outcome scales,69,76 and return to work.69 The figures below present the preoperative and postoperative functional scores over time for the uncontrolled studies (Figure 13), cohort studies (Figure 14), and trials (Figure 15) that examine mini-open RCR. The shape of the markers indicates the outcome scale used in the study, while the size is proportionate to the square root of the study sample size. The studies all indicate improvement in functional score from baseline to final followup, regardless of the outcome measure used and the study design (trial, cohort or uncontrolled study).

Figure 13 Uncontrolled studies examining functional outcomes for mini-open RCR

The figure presents the preoperative and postoperative functional scores over time for the uncontrolled studies that examine mini-open RCR. The studies all indicate improvement in functional score from baseline to final followup, regardless of the outcome measure used and the study design (trial, cohort or uncontrolled study).

Figure 14 Cohort studies examining functional outcomes for mini-open RCR

The figure presents the preoperative and postoperative functional scores over time for the cohort studies that examine mini-open RCR. The studies all indicate improvement in functional score from baseline to final followup, regardless of the outcome measure used and the study design (trial, cohort or uncontrolled study).

Figure 15 Trials examining functional outcomes for mini-open RCR

The figure presents the preoperative and postoperative functional scores over time for the trials that examine mini-open RCR. The studies all indicate improvement in functional score from baseline to final followup, regardless of the outcome measure used and the study design (trial, cohort or uncontrolled study).

Arthroscopic RCR. Twenty-seven uncontrolled studies (19 BA,70,74,80,84,90,91,100,110,111,120–124,130,142,158,161,169 five prospective cohorts with BA data,62,92,93,141,146 three retrospective cohorts with BA data149,150,162) examined the effectiveness of arthroscopic repair in patients with RC tears. The studies were published from 1993 to 2009 (median=2006; IQR: 2004 to 2007).

The total number of participants enrolled in the studies ranged from 16 to 193 (median=48 [IQR: 34 to 77]). The median duration of followup was 2.7 years (IQR: 2.2 to 3). The mean age of participants ranged from 42 to 70 years. The majority of the studies included on patients with full-thickness RC tears (n=15 studies, 56 percent), while the remaining studies included only partial-thickness tears,91,111,169 both tear types90,120,122,146,149,150 or did not report type of tear.123,142,161 Of the studies that reported tear size categories, eight included all tear sizes,84,93,121,123,130,141,142,158 two included small to large tears,74,122 three included small or medium tears only,70,90,110 and one study included only massive tears.62 One study reported including a small proportion of patients who were recreational athletes,91 while two studies including smokers.90,142 Manual labour jobs were reported in one study.80 Six studies reported including patients with a WCB claim74,80,84,91,130,149 and four studies reported excluding WCB patients.90,110,111,141

Health-related quality of life was reported in four studies,84,90,100,130 and all of the studies reported at least one functional outcome measure. Two studies reported return to work123 or physical activity.90 Cuff integrity was examined in 12 studies.74,80,84,90,92,110,121–124,142,158

The figures below present the preoperative and postoperative functional scores over time for the uncontrolled studies (Figure 16), cohort studies (Figure 17), and trials (Figure 18) that examine arthroscopic RCR. The shape of the markers indicates the outcome scale used in the study, while the size is proportionate to the square root of the study sample size. Regardless of the outcome measure used and the study design (trial, cohort or uncontrolled study), the studies all indicate improvement in functional score from baseline to final followup. Figure 19 plots the proportion of patients with and intact cuff after arthroscopic RCR over the followup period. The results were variable across the studies and showed no pattern with respect to study design.

Figure 16 Uncontrolled examining functional outcomes for arthroscopic RCR

The figure presents the preoperative and postoperative functional scores over time for the uncontrolled studies that examine arthroscopic RCR. Regardless of the outcome measure used and the study design (trial, cohort or uncontrolled study), the studies all indicate improvement in functional score from baseline to final followup.

Figure 17 Cohort studies examining functional outcomes for arthroscopic RCR

The figure presents the preoperative and postoperative functional scores over time for the cohort studies that examine arthroscopic RCR. Regardless of the outcome measure used and the study design (trial, cohort or uncontrolled study), the studies all indicate improvement in functional score from baseline to final followup.

Figure 18 Trials examining functional outcomes for arthroscopic RCR

The figure presents the preoperative and postoperative functional scores over time for the trials that examine arthroscopic RCR. Regardless of the outcome measure used and the study design (trial, cohort or uncontrolled study), the studies all indicate improvement in functional score from baseline to final followup.

Figure 19 Studies examining cuff integrity for arthroscopic RCR

The figure plots the proportion of patients with and intact cuff after arthroscopic RCR over the followup period. The results were variable across the studies and showed no pattern with respect to study design. Regardless of the outcome measure used and the study design (trial, cohort or uncontrolled study), the studies all indicate improvement in functional score from baseline to final followup.

RCR combination approaches. Seven uncontrolled studies (five BA89,104,116,160,168 and two prospective cohorts with BA data107,144) examined the effectiveness of RCR using a combination of approaches. Two studies used either an open or mini-open approach,116,168 two used either an open or arthroscopic approach,89,144 and three used one of open, mini-open or arthroscopic approaches when performing RCRs on the study participants.104,107,160 The studies were published between 2000 and 2008 (median=2007; IQR: 2005 to 2008).

The number of participants enrolled in the studies ranged from 38 to 125 (median=87 [IQR: 55 to 125]). The median duration of the followup period was 12 months (IQR: 12 to 14). Mean ages in the studies ranged from 56 to 64 years. Six studies included only patients with full-thickness tears, while the remaining study did not specify type of tear.168 All of the three studies reporting tear size included patients with a range of tear sizes.116,144,160 One study107 included patients with manual labour jobs, those with WCB claims and smokers.

Reported outcomes included health-related quality of life,107,160,168 functional measures,89,104,107,116,144,160 and cuff integrity.104,116,144 None of the studies reported time to return to work. Figure 20 presents the preoperative and postoperative functional scores over time for the all studies that examine a combination of RCR approaches. The shape of the markers indicates the outcome scale used in the study, while the size is proportionate to the square root of the study sample size. The studies all indicate improvement in score from baseline to followup, with the exception of one study in which CMS remained relatively stable over the 2 year followup period.

Figure 20 Studies examining functional outcomes for combined RCR approaches

The figure presents the preoperative and postoperative functional scores over time for the all studies that examine a combination of RCR approaches. The studies all indicate improvement in score from baseline to followup, with the exception of one study in which CMS remained relatively stable over the 2-year followup period.

Arthroscopic debridement. Three BA studies,65,156,166 assessed the effectiveness of the arthroscopic debridement in the RC tear population. The studies were published from 2000 to 2005 (median=2004; IQR: 2002 to 2005). The number of participants enrolled in the studies ranged from 14 to 33 (median=22 [IQR: 18 to 28]). The median followup duration was 3.1 years (IQR: 2.8 to 3.2). The mean age of participants was 69 years in two studies65,156 and not reported for one study.166 Two studies included only full-thickness tears65,156 and one study166 examined patients with partial- or full-thickness tears. For the two studies that reported tear size, one65 included only large RC tears and one156 included only massive RC tears.

All studies assessed function,65,156,166 while one study also assessed time to return to work.166 Health-related quality of life and cuff integrity were not examined in any of the studies. The preoperative and postoperative scores for all studies examining arthroscopic debridement are plotted in Figure 21. The shape of the markers indicates the outcome scale used in the study, while the size is proportionate to the square root of the study sample size. Similar to the other operative approaches, the scores consistently show marked improvement over time, regardless of the study design and outcome measure used.

Figure 21 Studies examining functional outcomes for arthroscopic debridement

The figure plots the preoperative and postoperative scores for all studies examining arthroscopic debridement. Similar to the other operative approaches, the scores consistently show marked improvement over time, regardless of the study design and outcome measure used.

Other approaches. Five BA studies82,95,101,126,127 assessed various other operative approaches in RC tear population. The studies were published from 1997 to 2007 (median=2005; IQR: 2002 to 2005). The number of participants enrolled in the studies ranged from 15 to 33 (median=21 [IQR: 19 to 23]). The median followup duration was 2.3 years (IQR: 2 to 2.7). For the four studies82,95,101,127 that reported age of participants, the mean age ranged from 51 to 63 years. Of the four studies that reported type of tear, three studies82,101,126 included only full-thickness RC tears and one study95 included partial- or full-thickness tears. Two studies95,101 included only massive RC tears, while tear characteristics were not reported in the other studies.82,126,127 Recreational athletes were included in one study.82 One study reported the proportion of patients manual labor jobs95 and two studies included patients with a workers’ compensation board (WCB) claim.95,101

Four studies95,101,126,127 used a functional outcome measure. Since the interventions varied widely, the preoperative and postoperative outcomes were not plotted on a graph.

#### Operative Technique—Comparative Studies

Summary. The variety of operative techniques compared across the included studies precludes conclusions and recommendations regarding most techniques. For all patient groups, regardless of technique, there were significant improvements in the postoperative functional, pain and range of motion outcome measures compared to preoperative scores. However, few of the techniques demonstrated clinically important differences between their respective groups on any of the postoperative measures. Overall the methodological quality of the studies was modest. There were six RCTs,71,73,78,81,98,105 one CCT117 and eight cohort studies.64,88,118,129,132,147,159,172

The most frequently studied techniques were single-row vs. double-row suture anchor fixation, which were compared in six studies.78,81,98,105,147,159 There was moderate evidence in favour of double-row repair for function based on a meta-analysis of all six studies. While the meta-analysis showed statistically significant results, the absolute differences in the change scores were small, rarely exceeding 5 points on an 100-point scale159 which puts into question the clinical importance of this finding. One study147 showed “clinically” and statistically significant difference in function favouring the double-row technique among the subgroup of patients with large or massive tears. There was also moderate evidence for cuff integrity: four of the studies78,81,98,159 examined this outcome, two of which reported a significant difference favouring double-row fixation.81,159 There was a low level of evidence for return to work: only one study81 examined return to work and found no significant difference between the two techniques.

A variety of other techniques were studied across the remaining nine studies. Two studies117,118 comparing mattress stitch vs. single stitch fixation. Each of the other seven studies examined a different comparison of techniques. Overall the level of evidence was low for these techniques. The outcome most often assessed was function. Only three studies found a significant difference between the groups examined: metal suture anchors vs. headed bioabsorbable corkscrews,88 bioabsorbable tacs vs. suture tying,64 and side-to-side vs. tendon-to-bone fixation71 showed a 15, 14 and 12 point differences on 100-point scales, respectively. Cuff integrity was assessed in five studies: a statistically significant difference was reported for mattress stitch vs. simple stitch in two studies,117,118 while no significant difference was found for non-absorbable vs. absorbable suture.73 No comparison was possible for transosseus vs. mattress suture,129 and staple fixation vs. side-to-side suture and anchor repair172 due to incomplete data reporting.

In summary, there is some evidence that double-row fixation may perform better than single-row in terms of cuff integrity but results suggest little difference for function. There are insufficient or low levels of evidence for the remaining operative techniques.

Results by individual study. Fifteen studies64,71,73,78,81,88,98,105,117,118,129,132,147,159,172 examined the effectiveness of different operative techniques for the repair of RC tears. The median sample size was 78 patients (IRQ: 55 to 100). The following operative techniques were assessed: single-row vs. double-row suture anchor repairs,78,81,98,105,147,159 bioabsorbable tacs vs. suture tying,64 side-to-side repair vs. tendon-to-bone fixation,71 nonabsorbable suture with Mason-Allen technique vs. absorbable sutures with Kessler technique,73 headed bio-corkscrews vs. metal anchor suture,88 mattress vs. simple stitch,117,118 mattress vs. single transosseous suture,129 ultrasonic suture welding vs. hand-tied knots,132 and staple fixation vs. side-to-side suture and anchor repair.172 With the exception of studies comparing single-row vs. double-row suture anchor repairs, the studies could not be pooled because the operative techniques were different. Patient and study characteristics, as well as study outcome data, are presented in Table 22 and Table 23, respectively. A grading of the body of evidence for operative technique studies is available in Table 24.

Table 22 Study and patient characteristics for studies assessing operative techniques

Author, year | Intervention (N participants Study design enrolled) | Age (yr), mean±SD (range)/Males, N (%) Other characteristics | Type of tear; size of tear Duration of symptoms (mo), mean±SD (range)
Bennett WF,64 2003 | G1: Bioabsorbable tacs (NR) G2: Suture tying (NR) Prospective cohort | G1: 58 yr/Males: 5 (56) G2: 64 yr/Males: 7 (70) | FTT; NR NR
Bigoni M,71 2009 | G1: Side-to-side repair (25) G2: Tendon-to-bone fixation (25) RCT | G1: NR/Males: 10 (40) WCB: 0 G2: NR/Males: 14 (56) WCB: 0 | FTT; Sm, Med, Lg NR
Boehm TD,73 2005 | G1: Nonabsorbable sutures (Mason-Allen technique) (50) G2: Absorbable sutures (Kessler technique) (50) RCT | G1: 56 yr (38–69)/Males: 36 (72) WCB: 5 (10) G2: 57 yr (41–71)/Males: 32 (64) WCB: 4 (8) | FTT; Sm, Med, Lg NR
Burks RT,78 2009 | G1: Double-row anchor RCR (20) G2: Single-row anchor RCR (20) RCT | G1: 57 (41–81)/Males: NR Smokers: 0 G2: 56 (43–74)/Males: NR Smokers: 0 | FTT; G1: 18 mm, G2: 19 mm NR
Charousset C,81 2007 | G1: Double-row anchor RCR (31) G2: Single-row anchor RCR (35) RCT | G1: 60 yr (37–62)/Males: 16 (52) Athletes: competitive 2 (6.5), recreational 2 (7) Manual Labourers: 6 (19) WCB: 2 (7) G2: 58 yr (32–74)/Males: 15 (43) Athletes: competitive 1 (3), recreational 5 (14) Manual Labourers: 10 (29) WCB: 4 (11) | NR; NR G1: 14.7 (1–73), G2: 11.9 (1–52)
Cummins CA,88 2003 | G1: Metal suture anchors (18) G2: Headed bio-corkscrews (9) Prospective cohort | G1: 63±8 yr/Males: 12 (67) G2: 58±10 yr/Males: 7 (78) | NR; G1: 1.9 cm^2^, G2: 1.1 cm^2^ NR
Franceschi F,98 2007 | G1: Double-row anchor RCR (30) G2: Single-row anchor RCR (30) RCT | G1: 59.6 yr (45–80)/Males: 16 (53) G2: 63.5 yr (43–76)/Males: 12 (40) | FTT; Lg, Mass ≥3 mo
Grasso A,105 2009 | G1: Double-row anchor RCR (40) G2: Single-row anchor RCR (40) RCT | G1: 55.2±6.5/Males: 18 (45) G2: 58.3±10.3/Males: 16 (40) | FTT; NR NR
Ko SH,117 2009 | G1: Massive cuff stitch (38) G2: Simple stitch (39) CCT | G1: 53.6 (40–68)/Males: 18 (47) G2: 52.4 (15–68)/Males: 17 (44) | FTT; 0.5–1.5 cm NR
Ko SH,118 2008 | G1: Modified mattress locking stitch (39) G2: Simple stitch (39) Prospective cohort | Total: 53.4 yr (39–68) | FTT; 1.5–3 cm NR
Matis N,129 2006 | G1: Transosseous single suture (75) G2: Transosseous mattress suture (24) Prospective cohort | G1: 58.2 yr (35–75)/Males: 51 (68) G2: 58.0 yr (35–75)/Males: 16 (67) | FTT/PTT; Sm, Med
McIntyre LF,132 2006 | G1: Suture welding (50) G2: Hand-tied knots (55) Retrospective cohort | G1: 55.7 yr (37–78)/Males: 29 (58) G2: 54.7 yr (17–78)/Males: 38 (69) | NR; G1: 3.4 cm (1–6), G2: 3.0 cm (1–6) G1: 9.9 mo (1–36), G2: 10.4 mo (1–36)
Park JY,147 2008 | G1: Double-row anchor RCR (42) G2: Single-row anchor RCR (43) Prospective cohort | G1 : 54.4 yr (28–76)/Males : 22 (52) G2 : 57 yr (39–78)/Males : 20 (47) | FTT; Sm, Med, Lg, Mass NR
Sugaya H,159 2005 | G1: Double-row anchor RCR (55 shoulders) G2: Single-row anchor RCR (51 shoulders) Retrospective cohort | G1 : 58.1 yr (36–73)/Males : 28 (51) G2 : 57.7 yr (34–72)/Males : 28 (55) | FTT; Sm, Med, Lg, Mass NR
Wilson F,172 2002 | G1: Staple fixation (35) G2: Side-to-side suture & anchor (65) Retrospective cohort | G1 : 49 yr (20–69)/Males : 27 (77) G2 : 52 yr (32–70)/Males : 38 (59) | FTT; Sm, Med, Lg G1: 48 wk (1–312), G2: 46 wk (2–312)

cm = centimeter; FTT = full-thickness tear; G = group; Lg = large; Mass = massive; Med = medium; NR = not reported; PTT = partial-thickness tear; RCR = rotator cuff repair; RCT = randomized controlled trial; SD = standard deviation; Sm = small; WCB = workers’ compensation board

Table 23 Outcome data for studies assessing operative techniques

Author, year | Intervention (N analysed) Followup, mean (range) | Outcome | Group 1 Baseline mean±SD (range)/Endpoint mean±SD (range) | Group 2 Baseline mean±SD (range)/Endpoint mean±SD (range) | Group 1 vs. Group 2 p-value
Bennett WF,64 2004 | G1: Bioabsorbable tacs (9) G2: Suture tying (10) NR (2–4 yr) | ASES | 33±15/88±12, p=0.001 | 31±23/72±11, p=0.002 | p=0.003^‡^
Bennett WF,64 2004 | G1: Bioabsorbable tacs (9) G2: Suture tying (10) NR (2–4 yr) | CMS^*^ | 50±10/77±12, p=0.001 | 55±16/77±8, p=0.001 | p=1.0^‡^
Bennett WF,64 2004 | G1: Bioabsorbable tacs (9) G2: Suture tying (10) NR (2–4 yr) | percent function | 36±16/86±17, p=0.001 | 47±16/83±12, p=0.002 | p=0.66^‡^
Bennett WF,64 2004 | G1: Bioabsorbable tacs (9) G2: Suture tying (10) NR (2–4 yr) | VAS pain | 7±2/1±1, p=0.001 | 7±3/2±2, p=0.002 | p=0.16^‡^
Bigoni M,71 2009 | G1: Side-to-side repair (NR) G2: Tendon-to-bone fixation (NR) 12 mo | CMS 3 mo 6 mo 12 mo | 32 (22–40) 41 (32–52) 70 (58–80) 78 (71–87), p<0.05 | 30 (22–38) 46 (38–53) 73 (58–83) 88 (81–94), p<0.05 | p<0.05
Bigoni M,71 2009 | G1: Side-to-side repair (NR) G2: Tendon-to-bone fixation (NR) 12 mo | ER Strength (%peak torque) 3 mo 6 mo 12 mo | 39 (32–56) 34 (38–47) 28 (22–38) 21 (12–30), p<0.05 | 37 (31–42) 32 (26–44) 24 (16–33) 12 (−22–26), p<0.05 | p<0.05
Bigoni M,71 2009 | G1: Side-to-side repair (NR) G2: Tendon-to-bone fixation (NR) 12 mo | IR Strength (% peak torque) 3 mo 6 mo 12 mo | 34 (25–40)/ 30 (26–55) 25 (18–35) 17 (11–25), p<0.05 | 32 (27–37)/ 25 (10–32) 14 (5–20) 9 (−8–20), p<0.05 | p<0.05
Boehm TD,73 2005 | G1: Nonabsorbable sutures (Mason-Allen technique) (49) G2: Absorbable sutures (Kessler technique) (44) 2.2 yr (2–2.5) | CMS | NR/78 | NR/76 | p=0.33
Boehm TD,73 2005 | G1: Nonabsorbable sutures (Mason-Allen technique) (49) G2: Absorbable sutures (Kessler technique) (44) 2.2 yr (2–2.5) | Pain (VAS–15 point) | NR/13.1 | NR/12.9 | p=0.65
Boehm TD,73 2005 | G1: Nonabsorbable sutures (Mason-Allen technique) (49) G2: Absorbable sutures (Kessler technique) (44) 2.2 yr (2–2.5) | Cuff integrity n/N (%), US | 38/49 (77.5) | 36/44 (81.8) | p=0.37
Burks RT,78 2009 | G1: Double-row anchor RCR (20) G2: Single-row anchor RCR (20) 12 mo | WORC | 31.8±19.4/87.9±20.0, p<0.0001 | 30.3±17.7/84.8±18.4, p<0.0001 | p=0.236
Burks RT,78 2009 | G1: Double-row anchor RCR (20) G2: Single-row anchor RCR (20) 12 mo | ASES | 37.6±19.3/85.5±20.0, p<0.0001 | 41.0±21.5/85.9±14.0, p<0.0001 | p=0.673
Burks RT,78 2009 | G1: Double-row anchor RCR (20) G2: Single-row anchor RCR (20) 12 mo | CMS | 45.6±20.3/74.4±18.4, p<0.0001 | 44.1±18.8/77.8±9.0, p<0.0001 | p=0.980
Burks RT,78 2009 | G1: Double-row anchor RCR (20) G2: Single-row anchor RCR (20) 12 mo | SANE | 40.8 ±21.6/89.9±20.0, p<0.0001 | 40.8±23.3/90.9±11.0, p<0.0001 | p=0.527
Burks RT,78 2009 | G1: Double-row anchor RCR (20) G2: Single-row anchor RCR (20) 12 mo | UCLA | 13.6±4.6/29.5±5.6, p<0.0001 | 12.1±3.9/28.6±3.6, p<0.0001 | p=0.165
Burks RT,78 2009 | G1: Double-row anchor RCR (20) G2: Single-row anchor RCR (20) 12 mo | Strength (Nm) | ER: 9.6±6.0/16.7±7.5, p<0.000 IR: 18.1±11.6/28.8±14.4, p<0.0001 | ER: 8.7±4.6/17.2±7.7, p<0.0001 IR: 15.8±7.9/28.1±13.8, p<0.0001 | p=0.862 p=0.687
Burks RT,78 2009 | G1: Double-row anchor RCR (20) G2: Single-row anchor RCR (20) 12 mo | Cuff integrity n/N (%), MRI | 18/20 (90) | 18/20 (90) | NS
Charousset C,81 2007 | G1: Double-row anchor RCR (28) G2: Single-row anchor RCR (33) 2.3 yr (2–3.3) | CMS^*^ | 53.6 (17–75)/82.7 (58–94), p<0.001 | 56.6 (33–77)/80.7 (62–95), p<0.001 | p=0.4
Charousset C,81 2007 | G1: Double-row anchor RCR (28) G2: Single-row anchor RCR (33) 2.3 yr (2–3.3) | Return to work, mean (range) mo; Number of patients | 4.2 (1–12); 12 | 5.3 (1–20); 14 | p=0.28
Charousset C,81 2007 | G1: Double-row anchor RCR (28) G2: Single-row anchor RCR (33) 2.3 yr (2–3.3) | Cuff integrity n/N (%), CTA 6 mo | 19/31 (61.3) | 14/35 (40.0) | p=0.03
Cummins CA,88 2003 | G1: Metal suture anchors (18) G2: Headed bio- corkscrews (9) 12 mo | CMS | NR/88±9 | NR/73±17 | p=0.016
Cummins CA,88 2003 | G1: Metal suture anchors (18) G2: Headed bio- corkscrews (9) 12 mo | ABD (degrees) 6 wk 3 mo 6 mo 12 mo | 113.6±8.1 112.8±7.3 120.8±8.0 144.8±4.6 164.4^†^ | 116.7±18.7 80.5±11.0 99.9±11.7 126.31±7.1 141.1±9.9^†^ | p<0.01
Cummins CA,88 2003 | G1: Metal suture anchors (18) G2: Headed bio- corkscrews (9) 12 mo | OSR 6 wk 3 mo 6 mo 12 mo | 1.4±0.6 3.1±0.2 3.3±0.2 3.4±0.2 3.6±0.1 | 1.1±1.3 2.3±0.3 2.5±0.2 2.5±0.4 3.1±0.3 | p<0.1 (significant)
Franceschi F,98 2007 | G1: Double-row anchor RCR (26) G2: Single-row anchor RCR (26) 22.5 mo (18 mo–2.1 yr) | UCLA | 10.1 (5–14)/33.3 (30–35), p<0.05 | 11.5 (6–14)/32.9 (29–35), p<0.05 | p>0.05
Franceschi F,98 2007 | G1: Double-row anchor RCR (26) G2: Single-row anchor RCR (26) 22.5 mo (18 mo–2.1 yr) | ROM (degrees) | F: 100 (30–150)/156 (140–170), p <0.05 ER: 79.6 (62–93)/131.3 (85–137), p <0.05 IR: 28.6 (22–35)/40.3 (26–43), p <0.05 | F: 110 (30–140)/159 (150–170), p<0.05 ER: 83.2 (65–95)/132.4 (90–140), p<0.05 IR: 27.3 (20–33)/37.3 (27–42), p<0.05 | p>0.05
Franceschi F,98 2007 | G1: Double-row anchor RCR (26) G2: Single-row anchor RCR (26) 22.5 mo (18 mo–2.1 yr) | Cuff integrity n/N (%), MRI 2 years | 18/26 (69.2) | 14/26 (53.8) | p>0.05
Grasso A,105 2009 | G1: Double-row anchor RCR (37) G2: Single-row anchor RCR (35) 24.8±1.4 mo | CMS^§^ | 73.2±19/100.5±17.8 | 77.5±14.7/104.9±21.8 | p=0.378
Grasso A,105 2009 | G1: Double-row anchor RCR (37) G2: Single-row anchor RCR (35) 24.8±1.4 mo | DASH \|\| | 37.8±18.2/12.7±10.1 | 38.9±15.8/15.4±15.6 | p=0.482
Grasso A,105 2009 | G1: Double-row anchor RCR (37) G2: Single-row anchor RCR (35) 24.8±1.4 mo | DASH-Work \|\| | 44.3±24.2/16.0±22.0 | 38.8±24.4/9.6±13.3 | p=0.212
Grasso A,105 2009 | G1: Double-row anchor RCR (37) G2: Single-row anchor RCR (35) 24.8±1.4 mo | Strength (lb) \|\| | 8.5±4.3/12.7±5.7 | 9.9±5.7/12.9±7.0 | p=0.382
Ko SH,117 2009 | G1: Massive cuff stitch (35) G2: Simple stitch (36) 2.8 yr (2–3.4) | ASES ADL | 10.1/26.8, p<0.05 | 10.7/26.6, p<0.05 | p>0.05
Ko SH,117 2009 | G1: Massive cuff stitch (35) G2: Simple stitch (36) 2.8 yr (2–3.4) | UCLA | 12.7/32.7, p<0.05 | 14.1/31.9, p<0.05 | p>0.05
Ko SH,117 2009 | G1: Massive cuff stitch (35) G2: Simple stitch (36) 2.8 yr (2–3.4) | Pain VAS | 7.0/1.1, p<0.05 | 7.0/1.1, p<0.05 | p>0.05
Ko SH,117 2009 | G1: Massive cuff stitch (35) G2: Simple stitch (36) 2.8 yr (2–3.4) | ROM (degrees) | F: NR/165.9 | F: NR/165.8 | p>0.05
Ko SH,117 2009 | G1: Massive cuff stitch (35) G2: Simple stitch (36) 2.8 yr (2–3.4) | Cuff integrity n/N (%), US | 30/35 (86) | 26/36 (72) | p<0.05
Ko SH,118 2008 | G1: Modified mattress locking stitch (NR) G2: Simple stitch (NR) 2.6 yr (2–3.1) | ASES (ADL score only) | 11/27, p<0.05 | 10.6/27.1, p<0.05 | p=0.99
Ko SH,118 2008 | G1: Modified mattress locking stitch (NR) G2: Simple stitch (NR) 2.6 yr (2–3.1) | UCLA | 13.4/32.7, p<0.05 | 13.7/31.9, p<0.05 | p>0.99
Ko SH,118 2008 | G1: Modified mattress locking stitch (NR) G2: Simple stitch (NR) 2.6 yr (2–3.1) | Pain (VAS) | 6.5/0.9, p<0.05 | 7/1.1, p<0.05 | p=0.08
Ko SH,118 2008 | G1: Modified mattress locking stitch (NR) G2: Simple stitch (NR) 2.6 yr (2–3.1) | Cuff integrity n/N (%), MRI (6–37 mo post- op) | 30/36 (83) | 24/33 (73) | p=0.03
Matis N,129 2006 | G1: Transosseous single suture (75) G2: Transosseous mattress suture (21) 23.8 mo (5 mo–4.9 yr) | CMS^*^ | 55.8 (29–78)/80.4 (59–105), p=NR | 59 (32–75)/83 (65–100), p=NR | NR
Matis N,129 2006 | G1: Transosseous single suture (75) G2: Transosseous mattress suture (21) 23.8 mo (5 mo–4.9 yr) | Cuff integrity n/N (%), US | 66/75 (88) | NR | NR
McIntyre LF,132 2006 | G1: Suture welding (47) G2: Hand-tied knots (40) 2.3 yr (18 mo–3.3 yr) | UCLA | 12.5/29.6, p<0.05 | 13.2/31.5, p<0.05 | p=0.297
Park JY,147 2008 | G1: Double-row anchor RCR (38) G2: Single-row anchor RCR (40) 2.1 yr (22 mo–2.5 yr) | ASES | 40.82±16.8/92.97±2.27, p<0.01 | 42.79 ±19.23/91.6±4.48, p<0.01 | p=0.09
Park JY,147 2008 | G1: Double-row anchor RCR (38) G2: Single-row anchor RCR (40) 2.1 yr (22 mo–2.5 yr) | CMS | 44.16±6.96/79.66±4.52, p<0.01 | 41.63±9.84/76.68±8.56, p<0.01 | p=0.06
Park JY,147 2008 | G1: Double-row anchor RCR (38) G2: Single-row anchor RCR (40) 2.1 yr (22 mo–2.5 yr) | SSI | ABD: 0.53±0.22/0.79±0.11, p<0.01 ER: 0.66±0.18/0.77±0.15, p<0.01 IR: 0.71±0.16/0.81±0.11, p<0.01 | ABD: 0.52±0.25/0.74±0.14, p<0.01 ER: 0.64±0.23/0.79±0.14, p<0.01 IR: 0.69±0.20/0.78±0.15, p=0.39 | p=0.81 p=0.57 p=0.78
Sugaya H,159 2005 | G1: Double-row anchor RCR (41) G2: Single-row anchor RCR (39) 2.9 yr (2–5) | ASES^*^ | 40.4±12.3 (10–65)/94.6±9.3 (60–100), p <0.01 | 45.8±19.4 (5–70)/92.9±12.1 (45–100), p <0.01 | p=0.49
Sugaya H,159 2005 | G1: Double-row anchor RCR (41) G2: Single-row anchor RCR (39) 2.9 yr (2–5) | UCLA^*^ | 14.4±4.5 (5–21)/33.1±3.4 (19–35), p<0.01 | 14.8±5.8 (3–22)/32.4±4.7 (16–35), p <0.01 | p=0.44
Sugaya H,159 2005 | G1: Double-row anchor RCR (41) G2: Single-row anchor RCR (39) 2.9 yr (2–5) | Cuff integrity n/N (%), MRI | 30/41 (73.2) [mean 14.4 mo] | 18/39 (46.2) [mean 13.6 mo] | p<0.01
Wilson F,172 2002 | G1: Staple fixation (35) G2: Side-to-side suture & anchor (65) 5 yr (2–14) | UCLA^*^ | 18.6/31.5 (14–35), p=NR | 21.1/32.5 (16–35), p=NR | p>0.05
Wilson F,172 2002 | G1: Staple fixation (35) G2: Side-to-side suture & anchor (65) 5 yr (2–14) | Cuff integrity n/N (%), Arthroscopy | 22/33 (66.7) | NR | NR

ABD = abduction; ADL = activities of daily living; ASES = American Shoulder and Elbow Surgeons score; CMS = Constant-Murley score; CTA = computed tomography arthrogram; ER = external rotation; F = flexion; G = group; IR = internal rotation; MRI = magnetic resonance imaging; N = number; NR = not reported; NS = not significant; OSR = Overall Shoulder Rating; RCR = rotator cuff repair; ROM = range of motion; SANE = Single Assessment Numeric Evaluation; SD = standard deviation; SSI = shoulder strength index; UCLA = University of California Los Angeles; US = ultrasonography; VAS = visual analogue scale

* Subscales reported

† Data extrapolated from graph

‡ Calculated by UAEPC

§ adjusted for baseline scores only

|| adjusted for baseline score, age, and gender

Table 24 Strength of evidence for operative techniques

Technique | Number of studies; subjects (analyzed)^*^ | Outcome | Strength of evidence domains | | | | | Strength of evidence
| | | Risk of bias | Consistency | Directness | Precision | Confounding
Single-row vs. double-row fixation | 1; 40 | HRQL | RCT Medium | Unknown | Direct | Imprecise | Absent | Low
Single-row vs. double-row fixation | 6; 435 (388) | Function | RCTs, cohorts Medium | Inconsistent | Direct | Precise | Absent | Moderate
Single-row vs. double-row fixation | 4; 270 (238) | Cuff integrity | RCTs, cohort Medium | Inconsistent | Direct | Precise | Absent | Moderate
Single-row vs. double-row fixation | 1; 66 | Time to return to work | RCT Medium | Unknown | Direct | Imprecise | Absent | Low
Bioabsorbable tacs vs. suture tying | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Bioabsorbable tacs vs. suture tying | 1; 31 (19) | Function | Cohort Low | Unknown | Direct | Imprecise | Present | Low
Bioabsorbable tacs vs. suture tying | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Bioabsorbable tacs vs. suture tying | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Side-to-side vs. tendon-to-bone fixation | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Side-to-side vs. tendon-to-bone fixation | 1 | Function | RCT Moderate | Unknown | Direct | Imprecise | Absent | Low
Side-to-side vs. tendon-to-bone fixation | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Side-to-side vs. tendon-to-bone fixation | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Nonabsorbable vs. absorbable sutures | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Nonabsorbable vs. absorbable sutures | 1; 100 | Function | RCT Medium | Unknown | Direct | Imprecise | Absent | Low
Nonabsorbable vs. absorbable sutures | 1; 100 | Cuff integrity | RCT Medium | Unknown | Direct | Imprecise | Absent | Low
Nonabsorbable vs. absorbable sutures | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Bio-corkscrews vs. metal suture | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Bio-corkscrews vs. metal suture | 1; 27 | Function | Cohort Medium | Unknown | Direct | Imprecise | Present | Low
Bio-corkscrews vs. metal suture | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Bio-corkscrews vs. metal suture | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Mattress stitch vs. simple stitch | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Mattress stitch vs. simple stitch | 2; 155 (149) | Function | CCT, cohort Medium | Inconsistent | Direct | Imprecise | Present | Low
Mattress stitch vs. simple stitch | 2; 155 (140) | Cuff integrity | CCT, cohort Medium | Consistent | Direct | Imprecise | Present | Moderate
Mattress stitch vs. simple stitch | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Transosseous mattress vs. single suture | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Transosseous mattress vs. single suture | 1; 99 | Function | Cohort Medium | Unknown | Direct | Imprecise | Present | Low
Transosseous mattress vs. single suture | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Transosseous mattress vs. single suture | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Ultrasonic welding vs. hand-tied knots | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Ultrasonic welding vs. hand-tied knots | 1; 105 | Function | Cohort Medium | Unknown | Direct | Imprecise | Present | Low
Ultrasonic welding vs. hand-tied knots | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Ultrasonic welding vs. hand-tied knots | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Staple fixation vs. side-to-side suture | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Staple fixation vs. side-to-side suture | 1; 100 | Function | Cohort Medium | Unknown | Direct | Imprecise | Present | Low
Staple fixation vs. side-to-side suture | 1; 100 (35) | Cuff integrity | Cohort Medium | Unknown | Direct | Imprecise | Present | Low
Staple fixation vs. side-to-side suture | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient

CCT = controlled clinical trial; HRQL = health-related quality of life; n/a = not applicable; RCR = rotator cuff repair; RCT = randomized controlled trial

* Number analyzed if different from number studied

Single-row vs. double-row suture anchor repairs. Six studies (four RCTs78,81,98,105 and two cohort studies147,159) compared single-row vs. double-row suture anchor repairs. Pooled results are shown in Figure 22 and Figure 23.

Figure 22 Single-row vs. double-row fixation on measures of functional outcome

Forest plot showing that the four RCTs and two cohort studies provided data for meta-analysis of the effects of single-row versus double-row suture anchor fixation on functional outcome measures. Data from the trials and cohort studies was analyzed separately. The following measures were included in the meta-analysis: ASES, CMS, DASH, UCLA score, and the ASES index. For all of the studies, the average change between preoperative and postoperative scores was compared between groups. The pooled estimate of change in function indicates a significant improvement in favor of double-row fixation (SMD=0.55; 95% CI, 0.02 to 1.07 for trials; SMD=0.78; 95% CI, 0.46 to 1.11 for cohort studies). There was heterogeneity between the trials (p=0.008; I2=75 percent); however, no evidence of heterogeneity between the two cohort studies (p=0.41; I2=0 percent)

Figure 23 Single-row vs. double-row fixation on cuff integrity

Forest plot showing three RCTs and one retrospective cohort study provided data for a meta-analysis of the effects of single-row versus double-row fixation on cuff integrity. Data from the trials and cohort study is presented separately. The pooled risk ratio from the trials shows no significant difference between double-row fixation over single-row fixation (SMD=1.20; 95% CI, 0.86 to 1.68). There was evidence of heterogeneity between the three RCTs (p=0.08; I2=60 percent), although this was not significant.

Burks et al.78 conducted a RCT comparing single-row vs. double-row fixation in patients with full-thickness tears. Twenty patients were randomly assigned to each intervention and followed for 12 months. The average tear size was 18 mm and 19 mm in the double-row and single-row groups, respectively. All patients were followed for 12 months and evaluated using the WORC, ASES, CMS, Single Assessment Numeric Evaluation tool, UCLA, strength and cuff integrity. There were significant preoperative to postoperative differences across all outcomes in both treatment arms, however no significant different were found between the groups. Eighteen of 20 patients in each group were found to have an intact rotator cuff based on MRI evaluation.

Charousset et al.81 conducted a RCT comparing single-row vs. double-row suture anchor repairs in patients who underwent arthroscopic RCR. Sixty-six patients were randomly assigned to the interventions (31 to double-row RCR, 35 to single-row RCR). All patients were followed for at least 2 years; mean followup was 2.3 years (range: 2 to 3.3). Patient function was evaluated using the CMS. At the date of last followup, the CMS had improved for both groups, but there was no statistically significant difference between the groups in the postoperative scores. Overall, more than 85 percent of patients who were employed prior to surgery returned to work. For the single-row group, the mean time to return to work was 5.3 months (range: 1 to 20); for the double-row group, it was 4.2 months (range: 1 to 12). The difference was not statistically significant (p=0.28). Cuff integrity was assessed using CT arthrography at 6 months following surgery. Anatomic healing was obtained in 14 (40.0 percent) cases in the single-row group compared with 19 (61.3 percent) in the double-row group. The difference was statistically significant (p=0.03), in favor of the double-row group.

Franceschi et al.98 conducted a RCT comparing single-row vs. double-row fixation in patients with large and massive full-thickness RC tears. All patients underwent arthroscopic RCR. Sixty patients were randomly assigned to the interventions (30 to each group); 52 (86.7 percent) were included in the final analyses. The mean length of followup was 22.5 months (range: 18 months to 2.1 years). Patients were evaluated using the UCLA shoulder scale and range of motion (flexion, external and internal rotation). For both groups, there was significant improvement in total UCLA scores and range of motion from preoperative assessment to the final postoperative evaluation. However, the differences between the groups in the postoperative scores for all measures were not statistically significant. Cuff integrity was assessed using MRI arthrography at 2 years following surgery. Intact tendons were shown in 14 (53.8 percent) patients in the single-row group compared with 18 (69.2 percent) in the double-row group. The difference between groups was not statistically significant.

Grasso et al.105 and colleagues conducted a RCT comparing single-row vs. double-row repair in 80 patients with large and massive full-thickness tears (40 patients per group). A total of 37 and 35 patients were evaluated at two year followup in the double-row and single-row fixation groups, respectively. Patients were assessed using the CMS, DASH, DASH-Work scales and strength. Substantial improvement was observed from preoperative to postoperative scores, however the statistical significance of these improvements were not reported. There were no significant between-group differences on any of the outcome measures.

Park et al.147 conducted a prospective cohort study comparing single-row vs. double-row fixation in patients undergoing arthroscopic RCR. Eighty-five patients were enrolled in the study (42 received double-row RCR, 43 received single-row RCR); 78 (91.7 percent) were included in the final analyses. All patients had full-thickness tears; tear size ranged from small or medium (n=46) to large or massive (n=32). The mean length of followup was 2.1 years (range: 22 months to 2.5 years). Patients were evaluated using the ASES index, the CMS and the Shoulder Strength Index (SSI; abduction, internal rotation and external rotation). For all patients, the mean postoperative ASES index and CMS improved significantly from the preoperative levels. The differences between the two groups on their postoperative scores for either measure were not statistically significant. Similarly, both groups had significant improvement in SSI after surgery, but the difference between the two groups was not statistically significant. The authors conducted a subgroup analysis of patients with tears less than 3 cm and those whose tears were greater than 3 cm. For patients with large or massive tears (>3 cm), the double-row fixture group showed clinically and statistically significant improvements in the ASES index, CMS, and SSI (abductor) than the single-row repair groups.

Sugaya et al.159 conducted a retrospective cohort study comparing single-row vs. double-row fixation in patients undergoing arthroscopic RCR. All patients had full-thickness tears; tear size ranged from small to massive. The mean length of followup was 2.9 years (range: 2 to 5). Patients were evaluated using the ASES index and the UCLA shoulder scale. Overall, 104 patients (106 shoulders) were enrolled in the study (55 received double-row RCR, 51 received single-row RCR). Of these, 80 (76.9 percent) were included in the final analyses. For all patients, the mean postoperative ASES and UCLA scores improved significantly from the preoperative levels. However, the differences between the two groups on their postoperative scores were not statistically significant. Postoperative MRI examination revealed 18 (46.2 percent) and 30 (73.2 percent) intact cuffs in the single-row vs. double-row anchorage groups, respectively. The difference between the groups was statistically significant (p<0.01).

The four RCTs78,81,98,105 and two cohort studies147,159 provided data for meta-analysis of the effects of single-row vs. double-row suture anchor fixation on functional outcome measures. Data from the trials and cohort studies was analyzed separately. The following measures were included in the meta-analysis: ASES,78 CMS,81 DASH,105 UCLA score,98 and the ASES index.147,159 For all of the studies, the average change between preoperative and postoperative scores were compared between groups. The pooled estimate of change in function indicates a significant improvement in favor of double-row fixation (SMD=0.55; 95% CI, 0.02 to 1.07 for trials; SMD=0.78; 95% CI, 0.46 to 1.11 for cohort studies). There was heterogeneity between the trials (p=0.008; I2=75 percent); however, no evidence of heterogeneity between the two cohort studies (p=0.41; I2=0 percent).

Three RCTs78,81,98 and one retrospective cohort study159 provided data for a meta-analysis of the effects of single-row vs. double-row fixation on cuff integrity (Figure 23). Data from the trials and cohort study is presented separately. The pooled risk ratio from the trials shows no significant difference between double-row fixation over single-row fixation (RR=1.20; 95% CI, 0.86 to 1.68). There was evidence of heterogeneity between the three RCTs (p=0.08; I2=60 percent), although this was not significant. The heterogeneity appears to be attributable to the addition of Burks et al;78 however, no differences between the patient characteristics across studies were apparent, with the exception of tear size. Burks78 included patients with medium tears, while patients in Franceschi98 had large or massive tears (tear size was not reported in Chraousset et al). Therefore, it is possible that double-row fixation may be result in greater probability of cuff integrity for patients with larger tears. The one cohort study showed a statistically significant difference in the proportion of patients whose cuff was found to be intact, in favor of the double-row group.

Bioabsorbable tacs vs. suture tying. Bennett et al.64 conducted a prospective cohort study comparing repair of the subscapularis tendon using 8 mm bioabsorbable tacs (Suretac; Accufex, Mansfield MA) with suture tying techniques using No. 2 Tevdeks and 5 mm metal screws (Metal Corkscrew; Arthrex, Naples FL). All patients had full-thickness tears and underwent arthroscopic repair and debridement. Thirty-one patients were enrolled in the study; 19 were included in the analysis (nine in the bioabsorbable tacs group, 10 in the suture tying group). Patients were allocated to the interventions based on tear patterns. Patients were followed for a minimum of 2 years (range: 2 to 4). Patient function was assessed using the ASES index, the CMS and a single question of percent function compared with the contralateral shoulder. A visual analogue scale was used to evaluate pain. Both groups showed significant improvement at endpoint compared to their baseline score (p<0.05) across all outcomes. The ASES score at final followup was significantly different between groups, favoring the bioabsorbable tacs group. All other outcomes showed no significant differences between groups.

Side-to-side vs. tendon-to-bone fixation. Bigoni and colleagues71 conducted a RCT comparing side-to-side repair vs. tendon-to-bone fixation in 50 patients with small, medium and large full-thickness tears. Twenty-five patients were randomized to each group. Patients were followed for 12 months and evaluated using the CMS and external and internal rotation strength. Significant improvement was shown in each of the study arms across all three outcomes. Further, there was a statistically significant difference between groups for the CMS and strength outcomes, favouring tendon-to-bone fixation.

Nonabsorbable vs. absorbable sutures. Boehm et al.73 conducted a RCT comparing transosseous repair using a modified Mason-Allen technique with nonabsorbable sutures (No. 3 Ethibond) vs. a modified Kessler technique with absorbable sutures (1.0 mm polydioxanone cord). All patients had full-thickness tears and underwent open RCR with acromioplasty. One hundred patients were randomly assigned to the interventions (50 to each group). All patients were followed for at least 2 years; mean followup was 2.3 years (range: 2 to 2.5) in the Mason-Allen group and 2.2 years (range: 2 to 2.4) in the Kessler group. Patients were assessed using the CMS and a visual analogue scale for pain. At the date of last followup, the CMS had improved for both groups, but there was no statistically significant difference between the groups in the postoperative scores. Similarly, there was no difference between the groups in terms of pain. Ultrasound was used to evaluate cuff integrity. There was no significant difference between the proportion of intact cuffs in the Mason-Allan group (77.5 percent) compared with the Kessler group (81.8 percent).

Headed bioabsorbable corkscrew vs. metal suture anchor. Cummins et al.88 conducted a prospective cohort study comparing Mitek RC metal suture anchors (Norwood, MA) vs. Headed Bio-Corkscrews (Arthrex, Naples, FL), a knotless device made of L-polylactic acid. All patients were treated with open RCR and acromioplasty. Twenty-seven patients were enrolled in the study (18 received metal suture anchors, 9 received corkscrews) and all were included in the analysis. In the group treated with suture anchors (n=18), the mean tear size was 1.9±1.0 cm^2^ (p=0.03); in the group treated with bioabsorbable screws (n=9), the mean tear size was 1.1±0.9 cm^2^. The CMS scoring system was used to assess shoulder function at 12 months following surgery. Based on the CMS, the suture anchors group demonstrated significantly higher function than the bioabsorbable screws group (88±9 vs. 73±17, p=0.016). Abduction improved for both groups, however there was a statistically significant difference at the 12 month followup favoring the metal suture anchor group (p<0.01). From 6 weeks to 12 months following surgery, the suture anchors group graded their “overall” shoulder rating higher than the corkscrew group (p<0.1); however, for both groups the overall rating was “fair.”

Mattress vs. simple stitch. Two studies compared the effectiveness of mattress stitch vs. simple stitch. Ko et al.118 conducted a prospective cohort study comparing a modified mattress locking stitch (MMLS), a simple modification of the Mason-Allen stitch, vs. a simple stitch in patients with a tear size ranging from 1.5 to 3.0 cm. The mean length of followup was 2.6 years (range: 2 to 3.1). Patients were evaluated using the ASES index, the UCLA shoulder scale and a visual analogue scale (VAS) for pain. Overall, 78 patients were enrolled in the study (39 per group). For all patients, the mean postoperative ASES index, UCLA score and VAS improved significantly from the preoperative levels. The differences between the two groups on their postoperative scores for all measures were not statistically significant. At 6 months to 3 years following surgery, MRIs were performed on 69 patients to examine cuff integrity. Repaired cuffs remained intact in 30 of 36 (83.3 percent) cases in the MMLS group compared with 24 of 33 (72.7 percent) in the simple stitch group (p=0.03).

In a second study, Ko and colleagues117 conducted a controlled clinical trial comparing a massive cuff stitch (mattress) repair with a simple stitch in patients with a tear size ranging from 0.5 to 1.5 cm. the mean followup was 2.8 years (range 2 to 3.4 years). A total of 38 and 39 patients were enrolled, and 35 and 36 patients were analyzed in the mattress stitch and simple stitch groups, respectively. There was significant improvement from preoperative to postoperative assessment for the ASES activities of daily living subscore, the UCLA and pain VAS. However, the only outcome that was significantly different between groups was cuff integrity, where 83 percent (30 of 36) of patients had an intact cuff in the the mattress stitch group, compared with 73 percent (24 of 33) of patients in the simple stitch group.

Figure 24 and Figure 25 below display the functional outcomes and cuff integrity of these two studies. Pooled estimates were not calculated, since the study designs differed (CCT vs. prospective cohort). Mattress stitch was favoured over simple stitch for functional outcomes in one study, while the second study showed no difference. Both studies found superior rates of cuff integrity in the mattress stitch group, however the differences between groups were not statistically significant.

Figure 24 Mattress stitch vs. simple stitch for measures of functional outcome

Forest plot showing the functional outcomes of two studies. Pooled estimates were not calculated, since the study designs differed (CCT versus prospective cohort). Mattress stitch was favored over simple stitch for functional outcomes in one study, while the second study showed no difference.

Figure 25 Mattress stitch vs. simple stitch for cuff integrity

Forest plot showing the cuff integrity of two studies. Pooled estimates were not calculated, since the study designs differed (CCT versus prospective cohort). Both studies found superior rates of cuff integrity in the mattress stitch group; however the differences between groups were not statistically significant.

Mattress vs. single transosseous suture. A prospective cohort study was conducted by Matis et al.129 to compare single transosseous suture vs. transosseous mattress suture in patients who underwent arthroscopic RCR and acromioplasty. Patients with full- and partial-thickness tears were included; tear size ranged from small to medium. Seventy-five patients were treated with transosseous sutures; the mean followup period was 2.2 years (range: 5 months to 4.9 years). Twenty-four patients were treated with mattress sutures; mean length of followup was 14.4 months (range: 4.8 months to 2.8 years). Patients were evaluated using the CMS. At the date of last followup, the CMS had improved for both groups. Cuff integrity was assessed by ultrasonography for the transosseus suture group. Intact tendons were shown in 66 cases (88 percent).

Ultrasonic suture welding vs. hand-tied knots. McIntyre et al.132 conducted a retrospective cohort study comparing ultrasonic suture welding using No. 2 polypropylene to fix the tendon vs. hand tied knots using No. 2 braided polyester suture. All patients were treated with a mini-open RCR and acromioplasty. The mean tear size was 3.4 cm (range: 1 to 6 cm) and 3.0 cm (range: 1 to 6 cm) in the suture welding and hand tied knot groups, respectively. The type of tear was not reported. Patients were evaluated using the UCLA shoulder scale. The mean length of followup for the suture weld group was 2.3 years (range: 18 months to 3.3 years). For patients treated with hand tied knots, 40/55 (72.7 percent) were available for followup compared to 47/50 (94.0 percent) for the suture weld group. For both groups, the mean postoperative UCLA score improved significantly from the preoperative levels. However, the difference between the two groups on their postoperative scores was not statistically significant.

Staple fixation vs. side-to-side suture. Wilson et al.172 conducted a retrospective cohort study comparing staple fixation (Instrument Makar, Okemos, MI) vs. side-to-side suture and anchor repair (G-4 or Stealth, Mitek, Westwood MA) in patients undergoing arthroscopic RCR. All patients had small to large sized full-thickness tears. One hundred patients were enrolled and included in the analysis (35 received staple fixation, 65 received side-to-side suture and anchor). The mean length of followup for the staple group was 7.9 years (3 to 14); for the suture anchors group it was 4 years (2 to 7). Patients were evaluated using the UCLA shoulder scale. For all patients, the mean postoperative UCLA score significantly improved from the preoperative levels. However, the difference between the two groups on their postoperative scores was not statistically significant. Cuff integrity was assessed in the staple fixation group. Of the 33 patients evaluated, the tendon was completely healed in 22 (66.7 percent).

#### Operative Augmentation—Comparative Studies

Summary. Three small comparative studies (32, 31, and 28 participants) were identified that assessed biologic augmentation of a RCR. One RCT109 and one retrospective cohort study170 comparing porcine small intestine submucosa xenograft vs. no augmentation found no statistically significant differences in functional scores or cuff integrity. In addition, the retrospective cohort study found a slower rate of resolution of pain during activities in the augmentation group and an almost global loss of strength, except for strength in external rotation, compared to the no augmentation group. The trial was at high risk of bias due to lack of blinding and baseline imbalances between groups, while the cohort study was limited by its retrospective design. One retrospective cohort study113 compared patch graft vs. no augmentation and found no statistically significant difference in function. The study evaluated range of motion for three movements and found a statistically significant difference favoring the patch for abduction (absolute difference between groups of 40 degrees), but no differences for flexion and external rotation. The study suffered from several methodological limitations including retrospective design, no control for confounding, and 25 percent loss to followup. Overall, the level of evidence is low for operative augmentations, which precludes any definitive conclusions in this area.

Results by individual study. Three studies (one RCT109 and two retrospective cohort studies113,170) compared the use of an operative biologic augmentation of RCR vs. no augmentation. The studies could not be pooled because operative augmentation devices or study designs were different. Patient and study characteristics, as well as study outcome data, are presented in Table 25 and Table 26, respectively. Grading of the body of evidence is presented in Table 27.

Table 25 Study and patient characteristics for studies assessing operative augmentations

Author, year | Intervention (N participants enrolled) Study design | Age (yr), mean±SD (range)/Males, N (%)Other characteristics | Type of tear; size of tear Duration of symptoms (mo), mean±SD (range)
Iannotti JP,109 2006 | G1: Porcine small intestine submucosa augmentation (16) G2: No augmentation (16) RCT | G1: 58 yr/Males: 11 (73) WCB : 3 (20) G2: 57 yr/Males: 6 (40) WCB: 0 (0) | FTT; Lg, Mass ≥ 3 mo
Ito J,113 2003 | G1: Patch graft (NR) G2: No augmentation (NR) Retrospective cohort | G1: 62.8±6.9 (49–70) yr/Males: 6 (67) G2: 52.3±8.6 (36–66) yr/Males: 10 (83) | FTT; Lg, Mass G1: 4.1±2.9 mo, G2: 5.8±4.7 mo
Walton JR,170 2007 | G1: Porcine small intestine submucosa augmentation (15) G2: No augmentation (16) Retrospective cohort | G1: 60.2±3.5 yr/Males: 10 (67) G2: 59.6±3.1 yr/Males: 11 (69) | FTT; Lg, Mass NR

FTT = full-thickness tear; G = group; Lg = large; mass = massive; NR = not reported; RCT = randomized controlled trial; SD = standard deviation; WCB = workers’ compensation board

Table 26 Outcome data for studies assessing operative augmentations

Author, year | Intervention (N analysed) Followup mean (range) | Outcome | Group 1 Pre-op mean±SD (range)/Post-op mean±SD (range) | Group 2 Pre-op mean±SD (range)/Post-op mean±SD (range) | Group 1 vs. Group 2 Post-op p-value
Iannotti JP,109 2006 | G1: Porcine small intestine submucosa augmentation (15) G2: No augmentation (15) 14 mo (12 mo–2.2 yr) | PENN^*^ | 42/83 (IQR: 70–92) | 34/91 (IQR: 81–99) | p=0.07
Iannotti JP,109 2006 | G1: Porcine small intestine submucosa augmentation (15) G2: No augmentation (15) 14 mo (12 mo–2.2 yr) | Cuff integrity n/N (%), MRI at 12 mo | 4/15 (26.7) | 9/15 (60.0) | p=0.11
Ito J,113 2003 | G1: Patch graft (9) G2: No augmentation (12) 3 yr (2–8.4) | JOA^*^ | 47.9±13.3/91.7±7.0, p=0.0077 | 54.2±9.7/92±7.6, p=0.0022 | p=0.19^†^
Ito J,113 2003 | G1: Patch graft (9) G2: No augmentation (12) 3 yr (2–8.4) | ROM (degrees) | F: 84.4±32.4/159.6±14.8, p=0.0005 ABD: 62.2±31.1/163.3±28.7, p=0.0007 ER: 43.9±16.9/41.7±24.7, p>0.05 | F: 94.6±43.9/145.8±27.1, p=0.0032 ABD: 85.0±43.9/146.4±27.1, p=0.0019 ER: 36.3±44.6/35.4±37.8, p>0.05 | F: p=0.10^†^ ABD: p=0.008^†^ ER: p=0.93^†^
Walton JR,170 2007 | G1: Porcine small intestine submucosa augmentation (15) G2: No augmentation (16) 2 yr | Pain during activities^§^ 3 mo 6 mo^‡^ 12 mo^‡^ 2 yr^‡^ | 11.0±1.4^‡^ 9.9±1.6 4.0±1.6 3.1 1.7 | 10.1±1.4^‡^ 4.0±1.3 4.3±2 3.7±1.3 3.1±1.2 | NS p<0.01 NS NS NS
Walton JR,170 2007 | G1: Porcine small intestine submucosa augmentation (15) G2: No augmentation (16) 2 yr | Strength^§^ (newton) | ER: NR/47±5 IR: NR/63±6 ADD: NR/70±7 Lift-off: NR/28±4 SS: NR/37±7 | ER: NR/67±11 IR: NR/99±11 ADD: NR/100±12 Lift-off: NR/61±11 SS: NR/58±9 | p=0.105 p<0.01 p<0.05 p<0.01 p=0.08
Walton JR,170 2007 | G1: Porcine small intestine submucosa augmentation (15) G2: No augmentation (16) 2 yr | Participation in sports | 2/15 (13.3) | 11/16 (68.8) | p<0.01
Walton JR,170 2007 | G1: Porcine small intestine submucosa augmentation (15) G2: No augmentation (16) 2 yr | Cuff integrity n/N (%), MRI | 4/10 (40.0) | 5/12 (41.6) | NS

ABD = abduction; ADD = adduction; ER = external rotation; F = flexion; G = group; IR = internal rotation; IQR = interquartile range; JOA = Japanese Orthopaedic Association scale; lb = pound; mo = month; MRI = magnetic resonance imaging; N = number; NR = not reported; NS = not significant; PENN = University of Pennsylvania Shoulder Score; pre-op = preoperative; post-op = postoperative; ROM = range of motion; SD = standard deviation; SE = standard error; SS = supraspinatus; yr = year

* Subscales reported

† Calculated by UAEPC

‡ Data extrapolated from a graph

§ Results expressed as the mean and standard error

Table 27 Strength of evidence for operative augmentation

Technique | Number of studies; subjects (analyzed)^*^ | Outcome | Strength of evidence domains | | | | | Strength of evidence
| | | Risk of bias | Consistency | Directness | Precision | Confounding
Porcine small intestine submucosa vs. no augmentation | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Porcine small intestine submucosa vs. no augmentation | 1; 32 (30) | Function | RCTs Medium | Unknown | Direct | Imprecise | Absent | Low
Porcine small intestine submucosa vs. no augmentation | 2; 63 (52) | Cuff integrity | RCT, cohort Medium | Unknown | Direct | Imprecise | Absent | Low
Porcine small intestine submucosa vs. no augmentation | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Patch graft vs. no augmentation | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Patch graft vs. no augmentation | 1; 28 (21) | Function | Cohort Low | Unknown | Direct | Imprecise | Present | Low
Patch graft vs. no augmentation | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Patch graft vs. no augmentation | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient

HRQL = health-related quality of life; n/a = not applicable; RCT = randomized controlled trial

* number analyzed if different from number studied

Porcine small intestine submucosa vs. no augmentation. Two studies compared augmention with porcine small intestine submucosa with no augmentation. Iannotti et al.109 conducted a RCT comparing porcine small intestine submucosa augmentation (Restore Orthobiologic Implant, DuPuy Orthopaedics, USA) vs. no augmentation in patients who underwent open RCR. All patients had large or massive full-thickness tears of the supraspinatus and infraspinatus tendons (two-tendon tears). Thirty-two patients were randomly assigned to the interventions (16 to each group); 30 were included in the final analyses. The mean length of followup was 14 months (12 mo to 2.2 yr). Patients were evaluated using the University of Pennsylvania Shoulder Score (PENN), which showed no significant difference between the groups at followup (p=0.07). Cuff integrity was assessed using MRI at 12 months following surgery. Anatomic healing was obtained in 4 (26.7 percent) cases in the porcine small intestine submucosa augmentation group compared with 9 (60 percent) in the group without augmentation. The difference was not statistically significant (p=0.11). The study authors suggest that the lack of statistically significant difference between the groups is attributable to the small sample size; this study was aborted early since it appeared that augmentation would not improve the rates of cuff integrity, the primary study outcome.

Walton et al.170 conducted a retrospective cohort study comparing porcine small intestine submucosa augmentation (Restore Orthobiologic Implant, DuPuy Orthopaedics, USA) vs. no augmentation using patients from an aborted RCT. Fifteen subjects (16 shlds) repaired with the xenograft were retrospectively matched to a group of 16 (16 shlds) subjects repaired by conventional RCR with no augmentation performed by the same surgeon and usually in the same time period. With matching, the control group was similar to the augmentation group with respect to the number of subjects, mean age, mean tear size and gender. All patients had poor tendon quality or large to massive tears with an intact subscapularis tendon. Patients were evaluated for pain during activity, strength, and cuff integrity during the 2 year followup period. No statistical difference in pain during activity was found, except at 3 months where patients with augmentation had significantly more pain with activity (p<0.01). In addition, patients with augmentation had significantly less participation in sports at the end of followup (p<0.05). Patients with xenograft had significantly less strength in liftoff, internal rotation and adduction (p<0.05) than patients with no augmentation. However, no significant differences in supraspinatus strength (p=0.08) and external rotation strength (p=0.105) were found between the groups. Cuff integrity was assessed using MRI at 2 years after surgery and the difference was not statistically significant. Anatomic healing was obtained in 4 (40.0 percent) cases in the xenograft group compared with 5 (41.6 percent) controls in the no augmentation group from participants available for imaging. Based on these findings, the authors do not recommend the use of the RESTORE Orthobiologic Implant.

Patch graft vs. no augmentation. Ito et al.113 conducted a retrospective cohort study comparing use of patch grafts, consisting of a double layer of freeze-dried fascia lata (Biodynamics, Germany), vs. no augmentation in patients with large or massive full-thickness RC tears. All patients underwent open RCR with acromioplasty. A total of 28 patients were enrolled in the study; 21 were included in the final analyses (9 in the patch graft group, 12 in the no augmentation group). The mean length of followup was 3 years (2 to 8.4). Patients were evaluated using the JOA score and range of motion (flexion, abduction, external rotation). For both groups, there was a significant difference in the JOA score, flexion and abduction from baseline to followup. A significant between-group difference was found for abduction range of motion, in favor of the patch graft group; for all other outcome measures, there were no significant differences between the patch and no patch groups.

#### Operative Augmentation—Uncontrolled Studies

Five BA studies67,99,152,155,174 evaluated the effectiveness of the operative augmentation in RC repair. Four studies67,99,155,174 assessed augmentation with open RCR, and one study152 assessed arthroscopic RCR with platelet-rich plasma augmentation. The studies were published from 2006 to 2008 (median=2007; IQR: 2006 to 2008).

The number of participants enrolled in the study ranged from 13 to 39 (median=23 [IQR: 20 to 32]). The median followup duration was 3.2 years (IQR: 2 to 3.6). The mean age of participants ranged from 54 to 67 years. All these studies included only patients with full-thickness tears. Medium to massive tears were included in one study,155 only massive RC tears in one study,174 and only large RC tears in one study.67 Tear size was not reported in two studies99,152. One study included smokers.155

All studies assessed function, while four assessed cuff integrity.67,99,155,174 Health-related quality of life and time to return to work were not reported for any of the studies. Figure 26 presents the preoperative and postoperative functional scores over time for all studies that examine operative augmentation with repair. The shape of the markers indicates the outcome scale used in the study, while the size is proportionate to the square root of the study sample size. Although the studies evaluated different types of augmentations, measured outcomes using different scales, had various followup durations and different study designs, they all indicate improvement in functional score from baseline to final followup. Figure 27 shows the proportion of patients with an intact rotator cuff at followup. While the BA studies showed a consistent trend of moderate to high cuff integrity, the one trial109 showed a poor outcome.

Figure 26 Studies examining functional outcomes for operative augmentation with repair

The figure plots the preoperative and postoperative functional scores over time for all studies that examine operative augmentation with repair. Although the studies evaluated different types of augmentations, measured outcomes using different scales, had various followup durations and different study designs, they all indicate improvement in functional score from baseline to final followup.

Figure 27 Studies examining cuff integrity for operative augmentation with repair

The figure shows the proportion of patients with an intact rotator cuff at followup. While the BA studies showed a consistent trend of moderate to high cuff integrity, one trial showed a poor outcome.

#### Postoperative Rehabilitation—Comparative Studies

Summary. Ten comparative studies evaluated postoperative rehabilitation. While most studies included some physical therapy component, the comparisons varied across studies.

- Three RCTs180,182,184 studied the addition of continuous passive motion to physical therapy. Overall, there was moderate evidence showing no difference in function or pain. One study182 showed a difference favouring continuous passive motion for time to 90 degrees abduction and time to return to work (absolute difference of 12 and 21 days, respectively). This suggests that continuous passive motion may affect the course of recovery over the short-term but not result in functional differences over the long-term. The trials were all at high risk of bias due to lack of blinding and inadequate allocation concealment.
- One CCT176 evaluated aquatic therapy in addition to a land-based program and found no differences in function or range of motion at the end of the study (12 weeks); however, there were significant differences between groups in flexion at the 3 and 6-week time-points (absolute differences 46.6 and 28.6 degrees, respectively). The study involved only 18 patients and had substantial methodological flaws.
- A prospective cohort study177 compared inpatients with day patients, all of whom underwent a structured rehabilitation regime. There were no significant differences in pain or range of motion over the 60-day followup.
- One RCT178 evaluated individualized physical therapy in addition to home exercise vs. home exercise alone and found no significant differences for function, range of motion, or strength over the 24 week followup.
- One RCT179 comparing a rehabilitation program with progressive loading to one with traditional loading found greater improvement in pain during activity and at rest (p<0.05), favouring the progressive loading group. No differences were found in function, range of motion or strength.
- One retrospective cohort study181 compared outcomes between inpatients in a rehabilitation center vs. outpatients attending rehabilitation at a private practice specializing in Concept Global d’Epaule. The Concept Global d’Epaule group had significantly less pain, yet no differences were found between groups for the CMS and strength scores.
- A retrospective cohort study183 comparing standardized vs. non-standardized physical therapy found that patients receiving standardized treatment had significantly greater improvement in function.
- One RCT185 compared videotape-based vs. physical therapy-based home exercise instruction and found no differences in function over the 54 week followup.

The evidence does not clearly identify treatments or treatment variations that alter the postoperative course of patients following RCRs; the overall level of evidence was low with few studies comparing any single therapeutic approach. There were significant differences over the course of postoperative followup for all patients but few significant differences between study groups. This may suggest a “ceiling effect:” patients may achieve their final functional outcome regardless of the type or intensity of the specific intervention. One issue that was consistently problematic across the studies was the poor reporting of physical therapy, both in terms of intervention components and delivery (frequency, intensity, dosage, etc). The studies in this area also suffer from a number of methodological flaws. Though there was a large proportion of RCTs, representing the highest level of evidence for therapeutic interventions, these were all at high risk of bias due to lack of blinding, missing outcome data, and/or inadequate concealment of allocation. Moreover, the studies tended to measure intermediate or surrogate outcomes (e.g., range of motion) rather than outcomes that may be most important to the patients, healthcare practitioners, and decisionmakers (e.g., health-related quality of life, time to return to work).

Results by individual study. Ten studies (six RCTs,178–180,182,184,185 one CCT176 and three cohort studies177,181,183) evaluated the effectiveness of various postoperative rehabilitation treatments. The median sample size was 61 patients (IQR: 36 to 80). The following postoperative rehabilitation techniques were assessed: continuous passive motion with physical therapy vs. physical therapy alone,180,182,184 aquatic and land-based therapy vs. land-based therapy alone,176 inpatient vs. day patient rehabilitation,177 home exercise with vs. without the addition of an individualized physical therapy program,178 progressive loading vs. traditional loading,179 inpatient rehabilitation vs. rehabilitation in a private practice specializing in Concept Global d’Epaule,181 standardized vs. non-standardized physical therapy program183 and videotape vs. physical therapy home exercise instruction.185 The outcomes of three studies evaluating the addition of continuous passive motion to physical therapy could be pooled in a meta-analysis, shown in Figure 28 and Figure 29. Patient and study characteristics, as well as study outcome data, are presented in Table 28 and Table 29, respectively. The grading of the body of evidence for postoperative rehabilitations studies is found in Table 30.

Figure 28 Continuous passive motion with physical therapy vs. physical therapy alone for measures of functional outcome

Forest plot showing two RCTs that provided data for meta-analysis of the effects of continuous passive motion versus no continuous passive motion on functional outcome measures. The CMS of Michael et al. and the shoulder score of Rabb were used in the analysis. The baseline to endpoint change scores were compared between groups. The pooled estimate showed no difference between the studies (SMD=0.08; 95% CI, -0.37 to 0.52). There was no evidence of heterogeneity between the studies (p=0.63; I2=0 percent).

Figure 29 Forest plot comparing pain in continuous passive motion vs. no continuous passive motion groups

Forest plot showing results of meta-analysis conducted comparing continuous passive motion versus no continuous passive motion for pain using two RCTs. The pain VAS in Michael et al. was compared with the pain subscore of the shoulder score index in Raab et al.184 using change scores. No differences was found between the interventions for pain (SMD=-0.12; 95% CI, -1.08 to 0.83) There was substantial heterogeneity between the two studies (p=0.05; I2=75 percent).

Table 28 Study and patient characteristics for studies assessing postoperative rehabilitations

Author, year | Intervention (N participants enrolled) Study design | Age (yr), mean±SD (range)/Males, N (%) Other characteristics | Type of tear; size of tear Duration of symptoms (mo), mean±SD (range)
Brady B,176 2008 | G1: Land-based & aquatic therapy program (12) G2: Land-based program (6) CCT | G1: 56.3±9 yr (41–67)/Males: 8 (67) G2: 53.5±16 yr (26–69)/Males: 3 (50) | NR; Sm, Med, Lg, Mass NR
Delbrouck C,177 2003 | G1: Inpatient rehabilitation (NR) G2: Day patient rehabilitation (NR) Prospective cohort | G1: 52.7±8 yr/Males: 25 (47) G2: 55±5 yr/Males: 16 (70) | PTT; Sm, Med, Lg, Mass NR
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (26) G2: Standardized home exercise regime (32) RCT | G1: 58±10 yr (41–81)/Males: 20 (77) WCB: 4 G2: 62±11 yr (42–83)/Males: 20 (63) WCB: 6 | PTT, FTT; G1: 5.0 cm^2^, G2: 6.0 cm^2^ G1: 12±16 mo (0–48 mo), G2: 19±27 mo (1–96 mo)
Klintberg IH,179 2009 | G1: Progressive loading (9) G2: Traditional loading (9) RCT | G1: NR/Males: NR G2: NR/Males: NR | FTT; Med, Lg, Mass NR
LaStayo PC,180 1998 | G1: CPM (17 shoulders) G2: Manual passive ROM exercises (15 shoulders) RCT | G1: 62.8 yr (30–80)/Males: 8 (47) G2: 63.7 yr (45–75)/Males: 6 (40) | NR; Sm, Med, Lg NR
Marc T,181 2009 | G1: Inpatient in rehab centre (26) G2: Private practice in CGE (38) G3: Inpatient and outpatient in CGE (16) Retrospective cohort | Total: 61 (36–80)/Males: 49 (61) | FTT; NR NR
Michael J,182 2005 | G1: CPM & PT program (40) G2: PT program (21) RCT | G1: 58 yr (35–70)/Males: 25 (63) Manual Labourers (light, moderate, heavy, overhead):12, 12, 6, 4 G2: 58 yr (43–71)/Males: 12 (57) Manual Labourers (light, moderate, heavy, overhead): 8, 6, 6, 1 | PTT, FTT; NR NR
Milroy DR,183 2008 | G1: Standardized PT (28) G2: Non-standardized PT (39) Retrospective cohort | G1: 57±10.9 yr/Males: 16 (57) G2: 57.8±9.81 yr/Males: 27 (69) | NR; NR NR
Raab MG,184 1996 | G1: CPM & PT (NR) G2: PT only (NR) RCT | G1: 54 yr/Males: 9 (64) G2: 58 yr/Males: 9 (75) | PTT, FTT; Sm, Med, Lg, Mass NR
Roddey TS,185 2002 | G1: Videotape instruction (NR) G2: PT instruction (NR) RCT | G1: 58.7±10.6 yr (34.6–78.0)/Males: 36 (67) G2: 57.2±9.1 yr (40.0–75.8)/Males: 33 (61) | FTT; G1: 2.5 cm (1–5 cm), G2: 2.6 cm (1.5–4.0 cm) NR

CCT = controlled clinical trial; CPM = continuous passive motion; FTT = full-thickness tear; G = group; Mass = massive; Med = medium; Lg = large; NR = not reported; PT = physical therapy; PTT = partial-thickness tear; RCT = randomized controlled trial; ROM = range of motion; SD = standard deviation; Sm = small; WCB = workers’ compensation board

Table 29 Outcome data for studies assessing postoperative rehabilitation

Author, year | Intervention (N analysed) Followup mean (range) | Outcome | Group 1 Baseline mean±SD (range)/Endpoint mean±SD (range) | Group 2 Baseline mean±SD (range)/Endpoint mean±SD (range) | Group 1 vs. Group 2 p-value
Brady B,176 2008 | G1: Land-based & aquatic therapy program (NR) G2: Land-based program (NR) 12 wk | WORC (95% CI) | 1163 (925–1402) | 1003 (482–1525) | p>0.05
Brady B,176 2008 | G1: Land-based & aquatic therapy program (NR) G2: Land-based program (NR) 12 wk | 3 wk | 1468±490^†^ | 1502±226^†^ | p>0.05
Brady B,176 2008 | G1: Land-based & aquatic therapy program (NR) G2: Land-based program (NR) 12 wk | 6 wk | 1267±289^†^ | 1335±500^†^ | p>0.05
Brady B,176 2008 | G1: Land-based & aquatic therapy program (NR) G2: Land-based program (NR) 12 wk | 12 wk | 635±260^†^, p<0.0001 | 728±421^†^, p<0.0001 | p>0.05
Brady B,176 2008 | G1: Land-based & aquatic therapy program (NR) G2: Land-based program (NR) 12 wk
Brady B,176 2008 | G1: Land-based & aquatic therapy program (NR) G2: Land-based program (NR) 12 wk | ROM (degrees) (95% CI) | F: 135 (125–145) | F: 141 (120–161)
Brady B,176 2008 | G1: Land-based & aquatic therapy program (NR) G2: Land-based program (NR) 12 wk | ROM (degrees) (95% CI) | ER: 31 (22–40) | ER: 30 (14–46)
Brady B,176 2008 | G1: Land-based & aquatic therapy program (NR) G2: Land-based program (NR) 12 wk | 3 wk | F: 59.8±26.6^†^ | F: 106.4±17.2^†^ | F/3 wks: p=0.005
Brady B,176 2008 | G1: Land-based & aquatic therapy program (NR) G2: Land-based program (NR) 12 wk | 3 wk | ER: 18.7±8.0^†^ | ER: 22.1±14.7^†^ | ER/p>0.05
Brady B,176 2008 | G1: Land-based & aquatic therapy program (NR) G2: Land-based program (NR) 12 wk | 6 wk | F: 94.3±26.6^†^ | F: 122.9±16.8^†^ | F/6 wks: p=0.01
Brady B,176 2008 | G1: Land-based & aquatic therapy program (NR) G2: Land-based program (NR) 12 wk | 6 wk | ER: 28.9±15.1^†^ | ER: 30.9±17.6^†^ | ER/p>0.05
Brady B,176 2008 | G1: Land-based & aquatic therapy program (NR) G2: Land-based program (NR) 12 wk | 12 wk | F: 148.7±16.8^†^, p<0.0001 | F: 160.1±9.8^†^, p<0.0001 | p>0.05
Brady B,176 2008 | G1: Land-based & aquatic therapy program (NR) G2: Land-based program (NR) 12 wk | 12 wk | ER: 67.5±17.4^†^, p<0.0001 | ER: 57.7±12.3^†^, p<0.0001 | p>0.05
Delbrouck C,177 2003 | G1: Inpatient rehabilitation (53 shoulders) G2: Day patient rehabilitation (23 shoulders) 60 days | Pain (VAS) | NR | NR | day 15: p=0.012
Delbrouck C,177 2003 | G1: Inpatient rehabilitation (53 shoulders) G2: Day patient rehabilitation (23 shoulders) 60 days | day 15 | 1.1 | 2.3 | day 30, 45, 60: p>0.05
Delbrouck C,177 2003 | G1: Inpatient rehabilitation (53 shoulders) G2: Day patient rehabilitation (23 shoulders) 60 days | day 30 | 1.3 | 2.0
Delbrouck C,177 2003 | G1: Inpatient rehabilitation (53 shoulders) G2: Day patient rehabilitation (23 shoulders) 60 days | day 45 | 1.2 | 2.2
Delbrouck C,177 2003 | G1: Inpatient rehabilitation (53 shoulders) G2: Day patient rehabilitation (23 shoulders) 60 days | day 60 | 0.7 | 1.2
Delbrouck C,177 2003 | G1: Inpatient rehabilitation (53 shoulders) G2: Day patient rehabilitation (23 shoulders) 60 days
Delbrouck C,177 2003 | G1: Inpatient rehabilitation (53 shoulders) G2: Day patient rehabilitation (23 shoulders) 60 days | ROM (degrees) | ABD: 146/118 | ABD: 153/128 | p>0.05
Delbrouck C,177 2003 | G1: Inpatient rehabilitation (53 shoulders) G2: Day patient rehabilitation (23 shoulders) 60 days | ROM (degrees) | F: 141/122 | F: 153/130 | p>0.05
Delbrouck C,177 2003 | G1: Inpatient rehabilitation (53 shoulders) G2: Day patient rehabilitation (23 shoulders) 60 days | ROM (degrees) | ER: 55/30 | ER: 61/31 | p>0.05
Delbrouck C,177 2003 | G1: Inpatient rehabilitation (53 shoulders) G2: Day patient rehabilitation (23 shoulders) 60 days | day 30 | ABD: 102 | ABD: 91 | p>0.05
Delbrouck C,177 2003 | G1: Inpatient rehabilitation (53 shoulders) G2: Day patient rehabilitation (23 shoulders) 60 days | day 30 | F: 109 | F: 104 | p>0.05
Delbrouck C,177 2003 | G1: Inpatient rehabilitation (53 shoulders) G2: Day patient rehabilitation (23 shoulders) 60 days | day 30 | ER: 18 | ER: 22 | p>0.05
Delbrouck C,177 2003 | G1: Inpatient rehabilitation (53 shoulders) G2: Day patient rehabilitation (23 shoulders) 60 days | day 45 | ABD: 100 | ABD: 125 | p>0.05
Delbrouck C,177 2003 | G1: Inpatient rehabilitation (53 shoulders) G2: Day patient rehabilitation (23 shoulders) 60 days | day 45 | F: 107 | F: 119 | p>0.05
Delbrouck C,177 2003 | G1: Inpatient rehabilitation (53 shoulders) G2: Day patient rehabilitation (23 shoulders) 60 days | day 45 | ER: 20 | ER: 23 | p>0.05
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | SSQ (95% CI) | 65 (57–73) | 75 (67–83)
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | 6 wk | 35 (28–42) | 35 (28–42) | p>0.05
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | 12 wk | 24 (15–33) | 30 (20–40) | p>0.05
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | 24 wk | 14 (7–21) | 32 (21–43) | p>0.05
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | ROM (passive, degrees) (95% CI) | F: 148 (139–157) | F: 134 (122–146)
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | ROM (passive, degrees) (95% CI) | ABD: 133 (122–144) | ABD: 120 (108–132)
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | ROM (passive, degrees) (95% CI) | ER: 55 (49–61) | ER: 47 (40–54)
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | 6 wk | F: 130 (118–142) | F: 111 (99–123) | p>0.05
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | 6 wk | ABD: 108 (93–123) | ABD: 95 (85–105) | p>0.05
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | 6 wk | ER: 34 (26–36) | ER: 31 (26–36) | p>0.05
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | 12 wk | F: 141 (129–153) | F: 136 (125–147) | p>0.05
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | 12 wk | ABD: 125 (110–140) | ABD: 119 (106–132) | p>0.05
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | 12 wk | ER: 42 (34–50) | ER: 41 (34–48) | p>0.05
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | 24 wk | F: 150 (142–158) | F: 144 (132–156) | p>0.05
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | 24 wk | ABD: 142 (130–154) | ABD: 130 (117–143) | p>0.05
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | 24 wk | ER: 51 (46–56) | ER: 43 (36–50) | p>0.05
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | Strength manual muscle test grades (median, 95% CI) | IR: 5 (5–5) | IR: 5 (5–5)
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | Strength manual muscle test grades (median, 95% CI) | ER: 5 (4.5–5) | ER: 5 (4.5–5)
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | Strength manual muscle test grades (median, 95% CI) | F: 4.5 (4.5–5) | F: 4.5 (4–4.5)
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | 6 wk | IR: 5 (5–5) | IR: 5 (5–5) | p>0.05
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | 6 wk | ER: 5 (4.5–5) | ER: 5 (4.5–5) | p>0.05
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | 6 wk | F: 4.5 (4–5) | F: 4.5 (4–4.5) | p>0.05
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | 12 wk | IR: 5 (5–5) | IR: 5 (5–5) | p>0.05
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | 12 wk | ER: 5 (5–5) | ER: 5 (4.5–5) | p>0.05
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | 12 wk | F: 4.5 (4–5) | F: 4.5 (4–5) | p>0.05
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | 24 wk | IR: 5 (5–5) | IR: 5 (5–5) | p>0.05
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | 24 wk | ER: 5 (5–5) | ER: 5 (5–5) | p>0.05
Hayes K,178 2004 | G1: Individualized PT & standard home exercise regime (20) G2: Standardized home exercise regime (22) 24 wk | 24 wk | F: 5 (4.5–5) | F: 5 (4.5–5) | p>0.05
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | CMS^‡^ (100-point) | NR | NR | NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 6 mo | 60 (50–84) | 76 (21–86) | NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 12 mo | 80 (67–97) | 78 (48–93) | NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 2 yr | 82 (72–93), NR | 77 (54–95), NR | NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | CMS^‡^ (75-point) | 35 (20–55) | 45 (24–75) | NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 6 mo | 51 (43–70) | 67 (21–74) | NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 12 mo | 69 (57–75) | 71 (45–75) | NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 2 yr | 71 (64–75), p<0.05 | 73 (51–75), NR | NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | FIS^‡^ | 54 (42–85) | 44 (6–77) | NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 6 mo | 34 (22–74) | 25 (5–64) | NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 12 mo | 19 (4–37) | 10 (0–50) | NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 2 yr | 1 (0–48), p<0.05 | 18 (0–36), p<0.05 | NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | Pain^‡^ during activity | 73 (54–98) | 60 (0–77) | 12 mo: NS^†^
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 6 mo | 28 (8–52) | 7 (0–50) | 24 mo: p<0.05
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 12 mo | 10 (5–50) | 7 (0–76)
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 24 mo | 2 (0–7), p<0.05 | 0 (0–40), p<0.05
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | Pain^‡^ at rest | 27 (12–64) | 4 (0–97) | 12 mo: p<0.05
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 6 mo | 1 (0–27) | 0 (0–15) | 24 mo: p<0.05
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 12 mo | 0 (0–0) | 0 (0–38)
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 24 mo | 0 (0–3), p<0.05 | 0 (0–12), NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | Active ROM^‡^ (degrees) | ABD: 140 (35–180) | ABD: 110 (40–180) | NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | Active ROM^‡^ (degrees) | F: 150 (90–170) | F: 150 (40–170) | NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | Active ROM^‡^ (degrees) | IR: 40 (35–65) | IR: 43 (40–90) | NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | Active ROM^‡^ (degrees) | ER (in ADD): 50 (30–60) | ER (ADD): 40 (10–50) | NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | Active ROM^‡^ (degrees) | ER (in ABD): 50 (5–90) | ER (ABD): 70 (40–110) | NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | Active ROM^‡^ (degrees) | EX: 40 (10–60) | EX: 45 (25–50) | NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | Active ROM^‡^ (degrees) | ABD: 163 (130–175) | ABD: 170 (150–180) | NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 6 mo | F: 140 (110–165) | F: 140 (60–165)
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 6 mo | IR: 48 (25–75) | IR: 40 (30–55)
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 6 mo | ER (in ADD): 43 (30–60) | ER (in ADD): 30 (20–60)
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 6 mo | ER (in ABD): 65 (25–100) | ER (in ABD): 70 (40–100)
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 6 mo | EX: 40 (25–45) | EX: 40 (30–50)
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 6 mo | ABD: 170 (140–180) | ABD: 175 (100–180)
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 12 mo | F: 150 (135–165) | F: 150 (110–175)
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 12 mo | IR: 50 (35–70) | IR: 45 (40–70)
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 12 mo | ER (in ADD): 40 (30–55) | ER (in ADD): 45 (20–60)
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 12 mo | ER (in ABD): 70 (15–90) | ER (in ABD): 90 (40–100)
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 12 mo | EX: 50 (30–60) | EX: 50 (30–60)
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 2 yr | NR | NR, p<0.05
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | Strength^‡^ | IR (J): 19 (12–32) | IR (J): 28 (5–63) | NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | Strength^‡^ | ER (J): 20 (9–33) | ER (J): 21 (1–37) | NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | Strength^‡^ | F (Nm): 107 (50–139) | F (Nm): 94 (0–214) | NR
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 6 mo | IR (J): 24 (16–50) | IR (J): 28 (11–41)
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 6 mo | ER (J): 15 (10–28) | ER (J): 25 (5–29)
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 6 mo | F (Nm): 108 (56–165) | F (Nm): 112 (0–197)
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 12 mo | IR (J): 28 (14–42) | IR (J): 37 (14–56)
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 12 mo | ER (J): 16 (10–32) | ER (J): 30 (7–36)
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 12 mo | F (Nm): 110 (62–186) | F (Nm): 124 (0–209)
Klintberg IH,179 2009 | G1: Progressive loading (7) G2: Traditional loading (7) 2 yr | 2 yr | NR | NR
Marc T,181 2009 | G1: Inpatient in rehab centre (26) G2: Private practice in CGE (38) G3: Inpatient and outpatient in CGE (16) 2 yr (minimum) | CMS | 45/80, NR | 50/85, NR | p=NS
Marc T,181 2009 | G1: Inpatient in rehab centre (26) G2: Private practice in CGE (38) G3: Inpatient and outpatient in CGE (16) 2 yr (minimum) | CMS | 45/80, NR | G3: 43/80, NR | p=NS
Marc T,181 2009 | G1: Inpatient in rehab centre (26) G2: Private practice in CGE (38) G3: Inpatient and outpatient in CGE (16) 2 yr (minimum)
Marc T,181 2009 | G1: Inpatient in rehab centre (26) G2: Private practice in CGE (38) G3: Inpatient and outpatient in CGE (16) 2 yr (minimum) | Pain improvement | 5.3, NR | 7.0, NR | G1 vs. G2: p<0.05 G1 vs. G3: p<0.05
Marc T,181 2009 | G1: Inpatient in rehab centre (26) G2: Private practice in CGE (38) G3: Inpatient and outpatient in CGE (16) 2 yr (minimum) | Pain improvement | 5.3, NR | G3: 7.3, NR | G1 vs. G2: p<0.05 G1 vs. G3: p<0.05
Marc T,181 2009 | G1: Inpatient in rehab centre (26) G2: Private practice in CGE (38) G3: Inpatient and outpatient in CGE (16) 2 yr (minimum)
Marc T,181 2009 | G1: Inpatient in rehab centre (26) G2: Private practice in CGE (38) G3: Inpatient and outpatient in CGE (16) 2 yr (minimum) | Strength (kg) | 3.5/6.5, NR | 4.5/7.5, NR | p=NS
Marc T,181 2009 | G1: Inpatient in rehab centre (26) G2: Private practice in CGE (38) G3: Inpatient and outpatient in CGE (16) 2 yr (minimum) | Strength (kg) | 3.5/6.5, NR | G3: 3.5/6.5, NR | p=NS
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | Pain VAS | NR | NR | p>0.05
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 1 wk | 4.9 | 8.0 | p>0.05
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 2 wk | 3.8 | 5.9 | p>0.05
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 4 wk | 1.7^†^ | 1.6^†^ | p>0.05
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr)
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | Passive ROM (deg) | ER: NR | ER: NR | p>0.05
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 12 wk | 48.4 | 56.3 | p>0.05
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 6 mo | 63.3 | 76.2 | p>0.05
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 12 mo | 80.5 | 99.4 | p>0.05
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 2 yr | 102.5^†^ | 129.8^†^ | p>0.05
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 2 yr | F: NR | F: NR | p>0.05
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 2 yr | 128.2 | 128.2 | p>0.05
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 2 yr | 141.8 | 146.3 | p>0.05
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 2 yr | 155.7 | 164.7 | p>0.05
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 2 yr | 170.7^†^ | 185.1^†^ | p>0.05
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | Active ROM (deg) | ER: NR | ER: NR
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 12 wk | 58.1 | 55.0
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 6 mo | 62.4 | 61.6
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 12 mo | 66.7 | 66.7
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 2 yr | 71.6^†^ | 71.6^†^
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 2 yr | F: NR | F: NR
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 2 yr | 114.1 | 102.0
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 2 yr | 128.1 | 113.3
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 2 yr | 142.5 | 124.6
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 2 yr | 158.4^†^ | 137.2^†^
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr)
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | Strength kg (SE) | ER: NR | ER: NR | p>0.05
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 6 mo | 9.9 (9.3–10.5) | 9.0 (8.4–9.9) | p>0.05
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 12 mo | 11.1 (10.4–11.9) † | 9.6 (8.8–10.4) † | p>0.05
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 12 mo | F: NR | F: NR | p>0.05
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 12 mo | 9.4 (8.9–9.9) | 8.0 (7.4–8.5) | p>0.05
Lastayo PC,180 1998 | G1: CPM (NR) G2: Manual passive ROM exercises (NR) 22±9.8 mo (6 mo–3.8 yr) | 12 mo | 10.3 (9.4–11.3) † | 9.6 (8.5–10.5) † | p>0.05
Michael J,182 2005 | G1: CPM & PT program (34) G2: PT program (21) 56 days | CMS | 39 (7–74)/69 (28–94) | 36 (13–57)/66 (27–96) | NR
Michael J,182 2005 | G1: CPM & PT program (34) G2: PT program (21) 56 days
Michael J,182 2005 | G1: CPM & PT program (34) G2: PT program (21) 56 days | Pain VAS | 62/41 | 62/29 | NR
Michael J,182 2005 | G1: CPM & PT program (34) G2: PT program (21) 56 days
Michael J,182 2005 | G1: CPM & PT program (34) G2: PT program (21) 56 days | Time until 90° ABD (days) | 31 days | 43 days | p=0.03
Michael J,182 2005 | G1: CPM & PT program (34) G2: PT program (21) 56 days
Michael J,182 2005 | G1: CPM & PT program (34) G2: PT program (21) 56 days | Return to work (mean days) | (21 days sooner than G2) | NR | NR
Milroy DR,183 2008 | G1: Standardized PT (NR) G2: Non-standardized PT (NR) NR | Mean difference on DASH (pts, 95% CI) | 12.4 (−1.60, −23.2) | | p≤0.05
Milroy DR,183 2008 | G1: Standardized PT (NR) G2: Non-standardized PT (NR) NR
Milroy DR,183 2008 | G1: Standardized PT (NR) G2: Non-standardized PT (NR) NR | Improvement in pain scores | NR | NR | p>0.05
Rabb MG,184 1996 | G1: CPM & PT (14) G2: PT only (12) 3 mo | Shoulder Score^*^ | 68/83, p>0.05 | 63/73, p>0.05 | p>0.05
Roddey TS,185 2002 | G1: Videotape instruction (54) G2: PT instruction (54) 52 wk (NR) | SPADI | 60.4±22.1 | 52.3±21.6
Roddey TS,185 2002 | G1: Videotape instruction (54) G2: PT instruction (54) 52 wk (NR) | 12 wk | 32.0±19.7 | 26.7±18.8 | p=0.17
Roddey TS,185 2002 | G1: Videotape instruction (54) G2: PT instruction (54) 52 wk (NR) | 24 wk | 18.1±16.1 | 15.3±15.2 | p=0.40
Roddey TS,185 2002 | G1: Videotape instruction (54) G2: PT instruction (54) 52 wk (NR) | 52 wk | 12.3±14.3 | 12.4±14.4 | p=0.99
Roddey TS,185 2002 | G1: Videotape instruction (54) G2: PT instruction (54) 52 wk (NR)
Roddey TS,185 2002 | G1: Videotape instruction (54) G2: PT instruction (54) 52 wk (NR) | PENN | 37.9±15.7 | 40.9±16.3
Roddey TS,185 2002 | G1: Videotape instruction (54) G2: PT instruction (54) 52 wk (NR) | 12 wk | 62.6±17.7 | 66.2±17.5 | p=0.32
Roddey TS,185 2002 | G1: Videotape instruction (54) G2: PT instruction (54) 52 wk (NR) | 24 wk | 79.4±15.5 | 79.6±17.3 | p=0.95
Roddey TS,185 2002 | G1: Videotape instruction (54) G2: PT instruction (54) 52 wk (NR) | 52 wk | 85.6±13.8 | 85.9±16.7 | p=0.94

ABD = abduction; ADD = adduction; CI = confidence interval; CMS = Constant-Murley score; CGE = Concept Global d’Epaule; CPM = continuous passive motion; DASH = Disabilities of the Arm, Shoulder and Hand; ER = external rotation; EX = extension; FIS = Functional Index of the Shoulder; G = group; IR = internal rotation; F = flexion; NR = not reported; NS = not significant; PT = physical therapy; pts = patients; ROM = range of motion; SD = standard deviation; SE = standard error; SSQ = Shoulder Service Questionnaire; SPADI = Shoulder Pain and Disability Index; UCLA = University of California Los Angeles Scale; PENN = University of Pennsylvania Shoulder Score; VAS = visual analogue scale; wk = week; WORC = Western Ontario Rotator Cuff Index; yr = year

* Subscales reported

† Data extrapolated from graph

‡ Values are presented as medians (range)

Table 30 Strength of evidence for postoperative rehabilitation

Technique | Number of studies; subjects (analyzed)^*^ | Outcome | Strength of evidence domains | | | | | Strength of evidence
| | | Risk of bias | Consistency | Directness | Precision | Confounding
Continuous passive motion with PT treatment vs. PT treatment | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Continuous passive motion with PT treatment vs. PT treatment | 3; 133 (122) | Function | RCTs | Consistent | Direct | Precise | Absent | Moderate
Continuous passive motion with PT treatment vs. PT treatment | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Continuous passive motion with PT treatment vs. PT treatment | 1; 61 (55) | Time to return to work | RCT Medium | Unknown | Direct | Imprecise | Absent | Low
Aquatic therapy with land-based therapy vs. land-based therapy | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Aquatic therapy with land-based therapy vs. land-based therapy | 1; 18 | Function | CCT Medium | Unknown | Direct | Imprecise | Absent | Low
Aquatic therapy with land-based therapy vs. land-based therapy | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Aquatic therapy with land-based therapy vs. land-based therapy | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Inpatient vs. day patient rehabilitation | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Inpatient vs. day patient rehabilitation | 0 | Function | n/a | n/a | n/a | n/a | n/a | Insufficient
Inpatient vs. day patient rehabilitation | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Inpatient vs. day patient rehabilitation | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Individualized PT program with home exercise vs. home exercise | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Individualized PT program with home exercise vs. home exercise | 1; 58 (42) | Function | Cohort Medium | Unknown | Direct | Imprecise | Absent | Low
Individualized PT program with home exercise vs. home exercise | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Individualized PT program with home exercise vs. home exercise | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Progressive vs. traditional loading | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Progressive vs. traditional loading | 1; 18 (14) | Function | RCT Medium | Unknown | Direct | Imprecise | Absent | Low
Progressive vs. traditional loading | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Progressive vs. traditional loading | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Inpatient rehab vs. outpatient CGE | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Inpatient rehab vs. outpatient CGE | 1; 80 | Function | Cohort Medium | Unknown | Direct | Imprecise | Absent | Low
Inpatient rehab vs. outpatient CGE | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Inpatient rehab vs. outpatient CGE | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Standardized vs. non-standardized PT program | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Standardized vs. non-standardized PT program | 1; 67 | Function | Cohort Medium | Unknown | Direct | Imprecise | Present | Low
Standardized vs. non-standardized PT program | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Standardized vs. non-standardized PT program | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Videotape vs. PT home exercise instruction | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Videotape vs. PT home exercise instruction | 1; 129 (108) | Function | RCT Medium | Unknown | Direct | Imprecise | Absent | Low
Videotape vs. PT home exercise instruction | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Videotape vs. PT home exercise instruction | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient

CGE = Concept Global d’Epaule; HRQL = health-related quality of life; n/a = not applicable; PT = physical therapy; RCT = randomized controlled trial;

* Number analyzed if different from number sudied

Continuous passive motion with physical therapy vs. physical therapy. Three studies assessed use of continuous passive motion, however the protocols and followup durations varied across the studies. Lastayo et al.180 conducted a RCT comparing the addition of continuous passive motion using a mechanical device (Thera-kinetics, Mount Laurel, New Jersey) vs. no continuous passive motion in patients who received manual range of motion and strengthening exercises. The former group received continuous passive motion for flexion and external rotation for four hours per day (three or four periods, each lasting 1–1.5 hours). All patients had undergone open RCR. Tear sizes ranged from small to large and were balanced between the two groups. Thirty-one patients (32 shoulders) were randomly assigned to the interventions (17 to continuous passive motion, 15 to no continuous passive motion). The mean length of followup was 22±9.8 months (6 months to 3.8 years). Patients were evaluated using the pain VAS score, passive and active range of motion, and isometric strength. There were no significant between-group differences in any of the outcome measures at any time points (p>0.05).

Michael et al.182 conducted a RCT comparing continuous passive motion using a mechanical device (five times per day at 20 minutes per session) plus a physical therapy program vs. physical therapy alone in patients who underwent open or mini-open RCR. The same physical therapy program was provided for both group and consisted of passive and active range of motion and strengthening exercise. All patients had partial- or full-thickness tears limited to the supraspinatus tendon. Sixty-one patients were randomly assigned to the interventions (40 to the continuous passive motion plus physical therapy group, 21 to the physical therapy group); 55 were included in the final analyses. The followup period was 56 days. Patients were evaluated using the CMS, the pain VAS score, time until 90 degree abduction was achieved, and time to return to work. There were no significant between-group differences for the CMS and pain scores. However, there was a significant difference between the groups in the postoperative duration needed until 90 degree abduction was achieved (p=0.03), in favour of the continuous passive motion group (31 vs. 43 days). The time to return to work was 21 days sooner in continuous passive motion group.

Rabb et al.184 conducted a RCT comparing continuous passive motion (8 hours per day) using a mechanical device (Thera-kinetics, Mount Laurel, New Jersey) plus a physical therapy program vs. physical therapy alone in patients who had RCR for a partial- or full-thickness tear. Tear size ranged from small to massive. The continuous passive motion plus physical therapy group had a much greater proportion of patients with large or massive tears (57 percent) compared to the physical therapy alone group (25 percent). Forty-one patients were randomly assigned to the interventions; 26 were included in the final analyses (14 in the continuous passive motion plus physical therapy group, 12 in the physical therapy group). Patients were evaluated at 3 months following surgery using a 100-point shoulder score. For both groups, there was no significant difference in the Shoulder score from baseline to endpoint (p>0.05). Similarly, there was no significant difference between the groups in the endpoint shoulder score (p>0.05).

Two RCTs182,184 provided data for meta-analysis of the effects of continuous passive motion vs. no continuous passive motion on functional outcome measures (Figure 28). The CMS of Michael et al.182 and the shoulder score of Rabb184 were used in the analysis. The baseline to endpoint change scores were compared between groups. The pooled estimate showed no difference between the studies (SMD=0.08; 95% CI, −0.37 to 0.52). There was no evidence of heterogeneity between the studies (p=0.63; I^2=^0 percent).

A meta-analysis was conducted comparing continuous passive motion vs. no continuous passive motion for pain using two RCTs (Figure 29). The pain VAS in Michael et al.182 was compared with the pain subscore of the shoulder score index in Raab et al.184 using change scores. No differences was found between the interventions for pain (SMD=−0.12; 95% CI, −1.08 to 0.83) There was substantial heterogeneity between the two studies (p=0.05; I^2=^75 percent). The heterogeneity may be partly attributable to a difference in the timing of outcome assessment; Michael et al.182 followed patients for 2 months, compared to Rabb et al.184 assessed patient outcomes at 3 months postoperatively.

Aquatic therapy with land-based therapy vs. land-based therapy. Brady et al.176 conducted a CCT comparing a combination aquatic and land-based program vs. a land-based program alone in patients who underwent RCR. Tear size ranged from small to massive and were balanced between groups. Eighteen patients were enrolled in the study (12 received aquatic and land-based treatment, 6 received only land-based treatment). All patients were evaluated at 3, 6, and 12 weeks postoperatively. The WORC Index and range of motion (flexion and external rotation) were used to assess patients. For both groups, there were significant differences in the WORC Index and range of motion from baseline to endpoint scores (p<0.0001). There were no significant differences between the groups at endpoint in the WORC Index or external rotation at any measurement point. At 3 and 6 weeks postoperatively, there were significant differences in flexion between the groups (p=0.005 and p=0.01, respectively), but not at 12 weeks (p>0.05).

Inpatients vs. day patient rehabilitation. Delbrouck et al.177 conducted a prospective cohort study comparing inpatient vs. day patient rehabilitation in patients who had undergone RCR. Patients had partial- or full-thickness tears; tears sizes ranged from small to massive and were similar between groups. Seventy-nine patients (84 shoulders) were enrolled in the study; 71 (76 shoulders) were included in the final analyses (53 in the inpatient group, 23 in the day patient group). Pain and range of motion were used to evaluate patients at various points over the 60-day followup period. Only one statistically significant difference was observed: pain at day 15 was less among the inpatient group, yet no difference was found at 30 days. Inpatients were more frequently prescribed NSAIDs and calcitonin for pain management compared with outpatients (11 and 4 patients, respectively). No other differences in pain or range of motion were observed.

Individualized physical therapy program with home exercise vs. home exercise. Hayes et al.178 conducted a RCT comparing individualized physical therapy with home exercise program vs. a home exercise program alone in patients who underwent open RCR. All patients received the same standardized home exercise regime, which was issued by the treating surgeon. Patients in the home exercise group received no other rehabilitation. For patients in the individualized physical therapy group, treatment content, rate of rehabilitation progression and total number of sessions were determined by the treating physical therapist. The treatment regime in this group may have consisted of any combination of exercises, manual therapy techniques, physical modalities of ice and moist heat, and rehabilitation and home exercise advice. Patients with full- and partial-thickness tears were included; the mean tear size was 5 cm^2^ in the individualized physical therapy with home exercise program group and 6 cm^2^ in the home exercise program group. Fifty-eight patients were randomly assigned to the interventions (26 to physical therapy and home exercise, 32 to the home exercise alone); 42 were included in the final analyses. Patients were revaluated at 6, 12, and 24 weeks postoperatively. The Shoulder Service Questionnaire (SSQ), passive range of motion (flexion, abduction, and external rotation), and manual muscle test for strength were used to assess patients. There were no differences between groups in any of the outcomes or measurement time points (p>0.05).

Progressive loading vs. traditional loading. A RCT was conducted by Klintberg and colleagues179 to compare the effectiveness of two physical therapy rehabilitation protocols, progressive vs. traditional loading, following RC surgery. In the progressive group, dynamic and specific muscle activation of the RC and passive range of motion was initiated the day after surgery. Loading of the shoulder progressively increased following 4 weeks of immobilization. In contrast, the traditional group was protected from RC loading and no specific exercises were introduced during the 6-weeks immobilization period. Eighteen patients were enrolled (nine per group) and 14 were assessed at 2-year followup. Patients were evaluated using the CMS, Functional Index of the Shoulder, pain VAS, active range of motion (abduction, flexion, internal rotation, external rotation, and extension) and strength (internal rotation, external rotation, and flexion). Significant preoperative to postoperative improvement was reported on the CMS for the progressive group, on abduction range of motion for the traditional group, and for the Functional Index of the Shoulder and pain scores in both groups. The only significant differences between the progressive and traditional groups were in pain during activity and at rest (p<0.05), favouring the progressive loading group.

Inpatient rehabilitation vs. outpatient rehabilitation focusing on Concept Global d’Epaule. A retrospective cohort study conducted by Marc et al.181 compared inpatient rehabilitation vs. rehabilitation in an outpatient center specializing in Concept Global d’Epaule (CGE) following RCR. A third study arm initially received inpatient rehabilitation and subsequently underwent outpatient care due to insufficiently improvement. CGE is a rehabilitation protocol based on three principles: (1) movements are done with pressure on humeral head to increase the subacromial space, (2) gradual progression from passive to active movement at patients tolerance, and (3) an attempt to restore dynamic equilibrium between muscles responsible for elevating the humeral head and the rotator cuff muscles. A total of 80 patients were enrolled, including 26, 38 and 16 in the inpatient, outpatient and combination groups, respectively. Patients were followed for a minimum of 2 years. Outcomes of interest included the CMS, pain and strength. The significance of baseline to endpoint scores was not reported. There was a significant difference between groups for pain, favouring the outpatient CGE group and the group with both inpatient rehabilitation and outpatient CGE treatment. No differences were found between groups for the CMS and strength scores.

Standardized vs. non-standardized physical therapy program. Milroy et al.183 conducted a retrospective cohort study comparing a standardized vs. non-standardized physical therapy program in patients who had had RCR. The treatment components of the physical therapy programs were not described. Sixty-seven patients were enrolled in the study (28 received standardized physical therapy, 39 received non-standardized physical therapy). Patients were evaluated using the DASH score and a numeric pain rating scale. There was significantly greater improvement on the DASH in the standardized physical therapy group (p ≤ 0.05). However, there were no differences between the groups in pain scores (p>0.05).

Videotape vs. physical therapy home exercise instruction. Roddey et al.185 conducted a RCT comparing videotape-based vs. physical therapy instruction home exercise programs in patients who had undergone arthroscopic repair. Patients in the first group received exercise instruction solely through a videotape given them by a physical therapist during their hospital stay. The second group received four one-on-one instruction sessions with a physical therapist throughout the course of the study. All patients had full-thickness RC tears. The mean tear size was 2.5 cm (1 to 5 cm) for the videotape-based instruction group and 2.6 cm (1.5 to 4.0) in the physical therapy instruction group. Overall, 129 patients were randomly assigned to the interventions, of which 108 were included in the final analyses (54 in each group). Patients were evaluated at 12, 24, and 54 weeks following surgery. The SPADI and the PENN shoulder scores were used to assess patients. There were no differences between the groups at any measurement time point for both the SPADI and the PENN indices (p>0.05).

#### Postoperative Rehabilitation—Uncontrolled Studies

Only one BA study evaluated a postoperative rehabilitation program consisting of passive and active stretching and strengthening exercises.175 The study was published in 2007 and enrolled 118 patients with a mean age of 67 years. The type and size of patient RC tears was not reported. There were 14 (12 percent) smokers among the included patients. The only outcome measure used to assess patients was the DASH scale. Since only one uncontrolled study evaluated postoperative rehabilitation, a visual display of the preoperative and postoperative scores is not presented.

### Question 3. Comparative Effectiveness of Nonoperative Treatments

The comparative effectiveness of nonoperative interventions was examined in a total of 10 studies (three comparative and seven uncontrolled studies). Various types of interventions were examined across the individual studies, including stretching and strengthening, steroid injections, oral medications.

#### Nonoperative—Comparative Studies

Summary. Only three comparative studies were identified that assessed nonoperative interventions. Pooling of data was not possible as the interventions compared in each study varied. One RCT194 compared sodium hyaluraonate vs. dexamethasone in terms of function and range of motion. The authors reported results comparing patients who were and were not satisfied with their degree of improvement within each group, therefore the data available did not allow for a head-to-head comparison regarding the relative efficacy of the two interventions under study. The trial was at high risk of bias due to a number of methodological weaknesses; in particular, the patient self-selection of treatment at 4 weeks based on satisfaction is an important source of bias. One retrospective cohort study191 compared rehabilitation focusing on protecting the cuff through reliance on other muscles (deltoid, pectoralis major and latissimus dorsi) vs. no rehabilitation and found statistically significant and clinically important differences favoring the rehabilitation group in terms of function (absolute difference between groups of 26.9 points on a 100-point scale). The study had several methodological limitations, most importantly a loss to followup of 46 percent. Differential loss to followup across the groups may yield exaggerated estimates of treatment effects. While rehabilitation may appear to be a promising intervention based on statistically and clinically important differences when compared to no rehabilitation, there is no evidence regarding how rehabilitation would compare to other interventions, such as steroid injections. Finally, a retrospective cohort study165 compared steroid injection vs. no steroid injection among participants undergoing physical therapy (not specified) and receiving oral medications (not specified). The results showed a significant difference in terms of function (absolute difference of 11 on an 83-point scale) and time to maximum range of motion (absolute difference of 4 months). The study had several methodological limitations which may bias the effects observed including retrospective timing and self-reporting of outcomes; further, the authors studied a select group which may affect generalizability of results beyond the population studied.

Overall, the level of evidence is low for nonoperative interventions due the variety of interventions examined across the body of evidence and methodological limitations of the individual studies. Treatment components were poorly described across the studies, both in term of content (e.g., components included in “physical therapy” treatment) and delivery (e.g., frequency, intensity), limiting the usefulness of the studies to clinicians attempting to determine the most effective ways to manage patients nonoperatively. In addition, outcomes such as range of motion were insufficiently described, as it was unclear whether active, active-assisted or passive motion was being assessed.

Results by individual study. Three studies (one RCT194 and two retrospective cohort studies165,191) compared the effectiveness of nonoperative treatments in patients with RC tears. The studies could not be pooled because different nonoperative interventions were compared in each study. Patient and study characteristics, as well as study outcome data, are presented in Table 31 and Table 32, respectively. Grading of the body of evidence is presented in Table 33.

Table 31 Study and patient characteristics for studies assessing nonoperative interventions

Author, year | Intervention (N participants enrolled) Study design | Age (yr), mean±SD (range)/Males, N (%)Other characteristics | Type of tear; size of tear Duration of symptoms (mo), mean±SD (range)
Shibata Y,194 2001 | G1: Sodium hyaluraonate (38) G2: Dexamethasone (40) RCT | G1: 59.5±9.1 yr/Males: 27 (71) Manual Labourers: 10 (26) G2: 62.4±8.6 yr/Males: 28 (74) Manual Labourers: 11 (28) | FTT; NR G1: 5.8±5.4 mo, G2: 4.7±5.7 mo
Leroux JL,191 1993 | G1: No rehabilitation (NR) G2: Rehabilitation (NR) Retrospective cohort | G1 and G2: 61.5 yr (36–85)/Males: (61) | FTT; NR 7.5±0.5 mo
Vad VB,165 2002 | G1: PT & oral medication (28) G2: PT & oral medication & steroid injections (12) Retrospective cohort | G1 and G2: 63.2 yr/Males: NR | FTT; Mass 6.3 mo (1–17)

FTT = full-thickness tears; G = group; Mass = massive; NR = not reported; PT = physical therapy; RCT = randomized controlled trial; SD = standard deviation

Table 32 Outcome data for studies assessing nonoperative interventions

Author, year | Intervention (N) Followup mean (range) | Outcome | Group 1 Baseline mean±SD (range)/Endpoint mean±SD (range) | | Group 2 Baseline mean±SD (range)/Endpoint mean±SD (range) | | Group 1 vs. Group 2 p-value
Shibata Y, 2001^194^ | G1: Sodium hyaluraonate (38) G2: Dexamethasone (40) 24 wk | UCLA^*^ | Satisfied patients (n=16) | Unsatisfied patients (n=22) | Satisfied patients (n=15) | Unsatisfied patients (n=25) | Satisfies vs. unsatisfied at 4wks: Group1: p<0.0001 Group2: p<0.0001
Shibata Y, 2001^194^ | G1: Sodium hyaluraonate (38) G2: Dexamethasone (40) 24 wk | Preoperative 4 wk 24 wk | 13.6±2.6 27.6±3.1, p<0.0001 26.2±3.1, p<0.0001 | 12.8±3.5 14.9±4.4 NR | 11.9±3.6 26.5±2.0, p<0.0001 25.3±2.5, p<0.0001 | 12.6±3.9 15.0±4.0 NR | Satisfies vs. unsatisfied at 4wks: Group1: p<0.0001 Group2: p<0.0001
Shibata Y, 2001^194^ | G1: Sodium hyaluraonate (38) G2: Dexamethasone (40) 24 wk | ROM (deg) 4 wk 24 wk | ABD:122.8±32.1 151.6±10.6, p<0.01 147.7±9.9, p≤0.05 ER: 43.8±12.7 52.2±10.6, p<0.001 49.6±9.0, p≤0.05 IR †: T12.3±1.8 T11.3±2.0, p≤0.05 T11.8±2.6, p>0.05 | ABD:124.3±44.2 130.7±36.8 NR ER: 54.1±22.8 55.5±19.7 NR IR † : T12.2±3.0 T10.6±3.1 NR | ABD:111.0±37.6 143.7±47.3, p<0.01 139.6±13.8, p≤0.05 ER: 37.3±15.1 45.3±7.2, p≤0.05 46.5±8.5, p≤0.05 IR †: L1.1±4.0 T12.3±2.8, p>0.05 NR, p>0.05 | ABD:117±47.3 112.4±38.2 NR ER: 46.8±20.0 39.0±18.3 NR IR †: L1.2±2.9 T12.6±3.1 NR | Satisfies vs. unsatisfied at 4wks: Group1: ABD: p≤0.05 ER: p>0.05 IR: p>0.05 Group2: ABD: p≤0.01 ER: p>0.05 IR: p>0.05
Leroux JL, 1993^191^ | G1: No rehabilitation (18) G2: Rehabilitation (42) 3.8 mo (5 days–2 yr) | SFI, baseline to endpoint change | −6.6±5.2, p>0.05 | | +20.3±2.5, p≤0.05 | | p<0.001
Vad VB, 2002^165^ | G1: PT & oral medication (28) G2: PT & oral medication & steroid injections (12) 3.2 yr (2–7) | Insalata^*^ | 44.4±1.7/63.6, p≤0.05 | | 44.4±1.7/74.5, p≤0.05 | | p≤0.05
Vad VB, 2002^165^ | G1: PT & oral medication (28) G2: PT & oral medication & steroid injections (12) 3.2 yr (2–7) | ROM (degrees) | ABD: 68/108, p<0.05 | | | | NR
Vad VB, 2002^165^ | G1: PT & oral medication (28) G2: PT & oral medication & steroid injections (12) 3.2 yr (2–7) | Time to maximum ROM (mo) | 9.3 (3–8) | | 5.3 (1–11) | | p≤0.05

ABD = abduction; deg = degree; ER = external rotation; G = group; Insalata = Insalata Shoulder Rating Questionnaire; IR = internal rotation; NR = not reported; PT = physical therapy; RCR = rotator cuff repair; ROM = range of motion; SD = standard deviation; SFI = Scapular Functional Index; UCLA = University of California Los Angeles Scale; wk = week; yr = year

* Subscales reported

† vertebral level (active ROM)

Table 33 Strength of evidence for nonoperative interventions

Technique | Number of studies; subjects (analyzed)^*^ | Outcome | Strength of evidence domains | | | | | Strength of evidence
| | | Risk of bias | Consistency | Directness | Precision | Confounding
Sodium hyaluraonate vs dexamethasone | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Sodium hyaluraonate vs dexamethasone | 1; 78 | Function | RCT Medium | Unknown | Direct | Imprecise | Absent | Low
Sodium hyaluraonate vs dexamethasone | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Sodium hyaluraonate vs dexamethasone | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Rehabilitation vs. no rehabilitation | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Rehabilitation vs. no rehabilitation | 1; 112 (60) | Function | Cohort Medium | Unknown | Direct | Imprecise | Present | Low
Rehabilitation vs. no rehabilitation | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Rehabilitation vs. no rehabilitation | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
PT, oral medications and steroid injection vs. PT, oral medications and no steroid injection | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
PT, oral medications and steroid injection vs. PT, oral medications and no steroid injection | 1; 40 | Function | Cohort Medium | Unknown | Direct | Imprecise | Absent | Low
PT, oral medications and steroid injection vs. PT, oral medications and no steroid injection | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
PT, oral medications and steroid injection vs. PT, oral medications and no steroid injection | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient

HRQL = health-related quality of life; n/a = not applicable; PT = physical therapy; RCT = randomized controlled trial

* Number analyzed if different from number studied

Sodium hyaluraonate vs. dexamethasone. Shibata et al.194 conducted a RCT comparing glenohumeral injection with sodium hyaluraonate or dexamethasone steroid in patients with full-thickness RC tears. The size of tears was not reported. Seventy-eight patients were randomly assigned to each intervention (38 to sodium hyaluraonate, 40 to dexamethasone). In addition, patient in both groups received Loxoprofen (180 mg/day) and physical therapy including heat and cuff strengthening exercise. All patients were evaluated at 4 weeks, at which point patients who were unsatisfied with their degree of improvement could elect to have surgical RCR. Only satisfied patients, who continued the nonoperative treatment to which they had been allocated, were assessed at 24 weeks using the UCLA shoulder score and range of motion (abduction, external and internal rotation). Compared to satisfied patients, those who were unsatisfied and opted for surgery at 4 weeks were more likely to have a manual labour job (p<0.01). At 4 weeks, there were significant differences between the satisfied and unsatisfied patients in the endpoint UCLA score and abduction, regardless of the type of nonoperative intervention to which they had been assigned. Satisfied patients showed significant improvement in UCLA score, abduction, and external rotation, but not internal rotation at 24 weeks compared with baseline measures. Head-to-head comparison of the two nonoperative interventions was not made.

Rehabilitation vs. no rehabilitation. Leroux et al.191 conducted a retrospective cohort study comparing rehabilitation with no rehabilitation in patients with full-thickness tears. The rehabilitation program focused on protecting the cuff through reliance on other muscles (deltoid, pectoralis major and latissimus dorsi). Overall, 112 patients were enrolled in the study; of these, 60 were included in the final analyses (42 in the rehabilitation group, 18 in the no rehabilitation group). The mean length of followup was 3.8 months (range: 5 days to 2 years). Patients were evaluated using the Scapular functional index, a 100-point functional scale with five components (pain, motility, function, power and stability). The difference in Scapular functional score from baseline to endpoint score was significant in the rehabilitation group (p≤0.05); however, this difference was not significant in the no rehabilitation group. There was a statistically significantly difference between the groups in the endpoint postoperative Scapular function score (p<0.001), in favour of the rehabilitation group.

Steroid vs. no steroid injection. Vad et al.165 conducted a retrospective cohort study comparing physical therapy with oral medication vs. physical therapy with oral medication and steroid injection. The study did not specify the components of the physical therapy treatment protocol, the type of oral medication or steroid, or specific site of steroid injection. All patients had massive full-thickness RC tears. Forty patients were enrolled in the study (12 received the steroid injection, 28 received no steroid). All patients were followed for at least 2 years; the mean followup duration was 3.2 years (range: 2 to 7). Patients were evaluated using the Insalata shoulder rating scale, range of motion (abduction), and time to maximum range of motion. For both groups, there were significant differences in the Insalata scores and range of motion from preoperative to postoperative scores (p≤0.05). Moreover, there were significant and clinically important differences between the group endpoint Insalata scores and time to maximum range of motion (p≤0.05), in favour of physical therapy with oral medication and steroid injection group.

#### Nonoperative Treatments—Uncontrolled Studies

Seven uncontrolled studies, including six BA186,197,189,190,192,193 and one prospective cohort with BA data,188 examined the effectiveness of nonoperative treatment for RC tears. Interventions evaluated in the studies included exercise protocols,187,188 programs consisting of analgesic, NSAID, steroid injection and reeducation interventions,186,190 pulsed radiofrequency ablation,189 anterior deltoid rehabilitation program,192 and early functional physical therapy and active shoulder support.193 The studies were published from 1991 to 2008, with 2006 the median year of publication (IQR: 2000 to 2008).

The number of participants enrolled in the studies ranged from 12 to 59 (median=29 [IQR: 21 to 42]). The median followup duration ranged from 25 days to 7 years (median=6 months). The mean age of participants ranged from 59 to 80 years. Full-thickness tears were included in three studies,187,190,192 both partial- and full-thickness tears were included in two studies,186,188 and two did not report type of tear.189,193 Only two studies reported tear size; one included all sizes187 and one included only massive tears.192 Recreational athletes and smokers were not reported in any of the studies. WCB patients were included in one study187 and manual labourers in another.186

Functional outcome measures were reported in all but one study.193 Only one study reported health-related quality of life186 and three reported proportion of patients who returned to work.186,187,190 Function was reported in six studies.186–190,192 Tendon healing were not reported in any of the nonoperative studies. Figure 30 presents the preoperative and postoperative functional scores over time for all studies that examine nonoperative treatments. The shape of the markers indicates the outcome scale used in the study, while the size is proportionate to the square root of the study sample size. Followup durations and the degree of improvement in outcome scores varied considerably across studies.

Figure 30 Studies examining functional outcomes for nonoperative treatments

Figure presents the preoperative and postoperative functional scores over time for all studies that examine nonoperative treatments. Followup durations and the degree of improvement in outcome scores varied considerably across studies.

### Question 4. Comparative Effectiveness of Nonoperative vs. Operative Treatments

The comparative effectiveness of nonoperative vs. operative interventions was examined in five comparative studies.

#### Nonoperative vs. Operative Treatments—Comparative Studies

Summary. Two RCTs and three cohort studies compared nonoperative treatment vs. operative RCR. The nonoperative treatments across the five studies varied in their components. Four studies66,165,196,197 included either physical therapy (treatment components not specified) or stretching and strengthening exercises, with or without the addition of steroid injections, oral medications, activity modification or manual therapy. One study195 examined the use of shock wave therapy. Nonoperative treatments were compared to either open or mini-open RCR. One study included a third comparison group undergoing arthroscopic debridement.165 All groups showed significant improvements over the study period regardless of the intervention. The majority of the studies showed significant difference in function, favouring repair over nonoperative interventions. However, the results were highly heterogeneous, with one study showing an absolute difference of 24.5 points on an 83-point scale in favour of the operative repair.165 This same study showed a significantly shorter time to maximum range of motion among the group undergoing arthroscopic debridement (3.2 months) compared to the nonoperative and open repair groups (6.8 months each). In general the level of evidence is low for nonoperative vs. operative interventions. The findings were inconsistent within and across studies. Further, as with complex interventions, it is difficult to determine the relative contributions of each of the components in the nonoperative treatment regimes.

Results by individual study. Five studies (two RCTs66,195 and three cohort studies165,196,197) compared nonoperative with operative treatment regimes. Pooled analyses are presented in Figure 31 and Figure 32. Summary tables of the patient characteristics and outcome data are available in Table 34 and Table 35. The body of evidence for key outcomes was graded and is shown in Table 36.

Figure 31 Nonoperative treatment vs. RCR for measures of functional outcome

Separate meta-analyses were conducted for the two trials and three cohort studies comparing the effects of nonoperative treatment versus surgical repair on functional outcome measures. The scales used to measure function included the ASES,66 CMS,196 Insalata,165 JOA,197 and the UCLA. Both of the trials significantly favored repair over nonoperative treatments for functional outcomes. For the cohort studies, the pooled estimate of change in function shows no significant difference between groups, although the surgical repair is favored (SMD=-1.34; 95% CI, -2.95, 0.27). There was substantial heterogeneity between the three studies (p〈0.0001, I2=92 percent), which may be attributed to differences in the nonoperative treatment components and the characteristics of the patients enrolled in each study.

Figure 32 Nonoperative treatment vs. RCR for pain

Two cohort studies provided data for meta-analysis for the effects of nonoperative treatment versus surgical repair on pain. The pain subscales of the CMS and JOA scales were used in this analysis. Baseline to followup change scores were compared between groups. The pooled analysis showed no statistically significant difference between the two treatments for pain (SMD=0.81; 95% CI, -1.26 to 2.88). Heterogeneity between the studies was substantial (p=0.001, I2=90).

Table 34 Study and patient characteristics for studies assessing operative vs. nonoperative interventions

Author, year | Intervention (N participants enrolled) Study design | Age (yr), mean±SD (range) / Males, N (%)Other characteristics | Type of tear; size of tear Duration of symptoms (mo), mean±SD (range)
De Carli,195 2006 | G1: Shock wave therapy (NR) G2: Mini-open RCR (NR) RCT | G1: NR / NR G2: NR / NR | FTT; NR NR
Lunn JV,196 2008 | G1: Steroid injection, PT & activity modification (14) G2: Open RCR (5) Prospective cohort | G1: 47.1 yr (30–66) / Males: 1 (7) G2: 46.2 yr (38–59) / Males: 3 (60) | FTT; NR 4.3 yr (6 mo–10 yr)
Moosmayer S,66 2010 | G1: PT (51) G2: Open / mini-open repair (52) G3: Secondary surgery (9)§ RCT | G1: 61±7.6 yr / Males: 36 (71) G2: 59±7.5 yr / Males: 37 (71) | FTT; Sm, Med G1: 9.8±9.8 mo; G2: 12.3±18.7 mo
Vad VB,165 2002 | G1: PT & oral medication (28) G2: PT, oral medication & steroid injection (12) G3: Open RCR (36) G4: Arthroscopic debridement (32) Retrospective cohort | G1 & 2: 63.2 yr / NR G3: 59.4 yr / NR G4: 62.9 yr / NR | FTT; Mass 6.3 mo (1–17 mo)
Yamada N,197 2000 | G1: Steroid injection, stretching, strengthening (14) G2: Open RCR (26) Retrospective cohort | G1: 70 yr (55–81) / Males: 9 (64) G2: 62 yr (47–82) / Males: 24 (92) | FTT; Mass G1: 44 mo (12 mo–11 yr); G2: 13 mo (1 mo–4.5 yr)

FTT = full-thickness tear; G = group; Mass = massive; Med = medium; mo = month; NR = not reported; PT = physical therapy; RCR = rotator cuff repair; RCT = randomized controlled trial; SD = standard deviation; Sm = small; yr = year

Table 35 Outcome data for studies assessing operative vs. nonoperative interventions

Author, year | Intervention (N analysed) Followup mean (range) | Outcome | Group 1 Baseline mean±SD (range)/ Endpoint mean±SD (range) | Group 2 Baseline mean±SD (range)/ Endpoint mean±SD (range) | Group 1 vs. Group 2 p-value
De Carli,195 2006 | G1: Shock wave therapy (NR) G2: Mini-open RCR (NR) G1: 24 (12–36) mo G2: 19 (12–26) mo | ASES | 47 / 70, p<0.05 | 50 / 87, p<0.05 | p<0.05
De Carli,195 2006 | G1: Shock wave therapy (NR) G2: Mini-open RCR (NR) G1: 24 (12–36) mo G2: 19 (12–26) mo | CMS | 33 / 67, p<0.05 | 30 / 77, p<0.05 | NR
De Carli,195 2006 | G1: Shock wave therapy (NR) G2: Mini-open RCR (NR) G1: 24 (12–36) mo G2: 19 (12–26) mo | UCLA | 11 / 27, p<0.05 | 11 / 32, p<0.05 | p<0.05
Lunn JV, 2008^196^ | G1: Steroid injection, PT & activity modification (14) G2: Open RCR (5) 4.2 yr (2–6.6) | CMS^*^ | 53 (32–78.5) / 69.5 (44–95), p=0.009 | 51 (24.5–65) / 66.6 (37.5–87), p=0.009 | p=0.61
Lunn JV, 2008^196^ | G1: Steroid injection, PT & activity modification (14) G2: Open RCR (5) 4.2 yr (2–6.6) | ROM (degrees; affected, normal sides) | NR | F: NR / 158, 176 (NR by group) ER: NR / 48, 58 IR: NR/ T12, T7 | NR
Lunn JV, 2008^196^ | G1: Steroid injection, PT & activity modification (14) G2: Open RCR (5) 4.2 yr (2–6.6) | Strength (kg; affected, normal sides) | NR | ER: NR / 3.2, 6, p<0.0001 (NR by group) | NR
Lunn JV, 2008^196^ | G1: Steroid injection, PT & activity modification (14) G2: Open RCR (5) 4.2 yr (2–6.6) | Cuff integrity n/N (%), MRI | 3 / 5 (60) | NR | NA
Moosmayer S,66 2010 | G1: PT (51) G2: Open / mini-open repair (51) G3: Secondary surgery (9)^§^ 12 mo | SF-36 (95%CI) 6 mo 12 mo 6 mo 12 mo | PCSS: 38.6 (36.2–41.1) 47.3 (44.7–50.0) 48.9 (46.0–51.7), p=NR MCSS: 57.3 (54.7–59.9) 57.6 (55.5–59.7) 57.5 (55.4–59.5), p=NR | PCSS: 38.2 (36.6–39.9) 47.9 (45.3–50.4) 50.7 (47.8–53.6), p=NR MCSS: 54.1 (50.9–57.3) 57.5 (55.0–60.0) 56.2 (53.7–58.8), p=NR | G1 vs. G2: PCSS: 0.84>p>0.10^‡^ MCSS: 0.92>p>0.29^‡^ G2 vs. G3: NR
Moosmayer S,66 2010 | G1: PT (51) G2: Open / mini-open repair (51) G3: Secondary surgery (9)^§^ 12 mo | SF-36 (95%CI) 6 mo 12 mo 6 mo 12 mo | PCSS: 38.6 (36.2–41.1) 47.3 (44.7–50.0) 48.9 (46.0–51.7), p=NR MCSS: 57.3 (54.7–59.9) 57.6 (55.5–59.7) 57.5 (55.4–59.5), p=NR | G3: NR | G1 vs. G2: PCSS: 0.84>p>0.10^‡^ MCSS: 0.92>p>0.29^‡^ G2 vs. G3: NR
Moosmayer S,66 2010 | G1: PT (51) G2: Open / mini-open repair (51) G3: Secondary surgery (9)^§^ 12 mo | ASES^*^(95%CI) 6 mo 12 mo | 48.2 (44.1–52.2) 75.8 (70.2–81.4) 79.2 (72.7–85.5), p=NR | 45.5 (41.5–49.6) 84.5 (80.3–88.6) 92.6 (88.6–96.6), p=NR | G1 vs. G2: p<0.0005^‡^ G2 vs. G3: NR
Moosmayer S,66 2010 | G1: PT (51) G2: Open / mini-open repair (51) G3: Secondary surgery (9)^§^ 12 mo | ASES^*^(95%CI) 6 mo 12 mo | 48.2 (44.1–52.2) 75.8 (70.2–81.4) 79.2 (72.7–85.5), p=NR | G3: 42.1 (30.1–54.2) Pre-op\|\|: 48.9 (32.6–65.2) 6 mo: 75.4 (59.2–91.7) 12 mo: 88.9 (77.4–100.0), p=NR | G1 vs. G2: p<0.0005^‡^ G2 vs. G3: NR
Moosmayer S,66 2010 | G1: PT (51) G2: Open / mini-open repair (51) G3: Secondary surgery (9)^§^ 12 mo | CMS^*^ (95%CI) 6 mo 12 mo | 38.4 (34.4–42.4) 64.1 (58.5–69.7) 66.8 (60.6–73.1), p=NR | 35.3 (31.6–39.0) 64.9 (60.2–69.7) 76.8 (72.6–80.9), p=NR | G1 vs. G2: p=0.002^‡^ G2 vs. G3: NR
Moosmayer S,66 2010 | G1: PT (51) G2: Open / mini-open repair (51) G3: Secondary surgery (9)^§^ 12 mo | CMS^*^ (95%CI) 6 mo 12 mo | 38.4 (34.4–42.4) 64.1 (58.5–69.7) 66.8 (60.6–73.1), p=NR | G3: 36.2 (27.3–45.2) Pre-op\|\|: 35.9 (26.9–44.9) 6 mo: 57.9 (43.8–72.0) 12 mo: 69.8 (55.1–84.4), p=NR | G1 vs. G2: p=0.002^‡^ G2 vs. G3: NR
Moosmayer S,66 2010 | G1: PT (51) G2: Open / mini-open repair (51) G3: Secondary surgery (9)^§^ 12 mo | Cuff integrity n/N (%),MRI 12 mo | NR | 38 / 50 (76) ¶ | G1 vs. G2: NR G2 vs. G3: p=0.67^‡^
Moosmayer S,66 2010 | G1: PT (51) G2: Open / mini-open repair (51) G3: Secondary surgery (9)^§^ 12 mo | Cuff integrity n/N (%),MRI 12 mo | NR | 8 / 9 (89) | G1 vs. G2: NR G2 vs. G3: p=0.67^‡^
Vad VB, 2002^165^ | G1 & G2: PT & oral medication (± steroid injection) (40) G3: Open RCR (36) G4: Arthroscopic debridement (32) 3.2 yr (2–7) | Insalata | G1 & G2: 44.4±1.7 / 70.5±1.4, p≤0.05 | G3: 33±1.2 / 83.6±1.4, p≤0.05 | p<0.01^‡^ p<0.01^‡^
Vad VB, 2002^165^ | G1 & G2: PT & oral medication (± steroid injection) (40) G3: Open RCR (36) G4: Arthroscopic debridement (32) 3.2 yr (2–7) | Insalata | G1 & G2: 44.4±1.7 / 70.5±1.4, p≤0.05 | G4: 42.3±1.4 / 81.4±1.3, p≤0.05 | p<0.01^‡^ p<0.01^‡^
Vad VB, 2002^165^ | G1 & G2: PT & oral medication (± steroid injection) (40) G3: Open RCR (36) G4: Arthroscopic debridement (32) 3.2 yr (2–7) | ROM (degrees) | G1 & G2: ABD: 68 / 108, p≤0.05 | G3: ABD: 72 / 116, p≤0.05 | NR
Vad VB, 2002^165^ | G1 & G2: PT & oral medication (± steroid injection) (40) G3: Open RCR (36) G4: Arthroscopic debridement (32) 3.2 yr (2–7) | ROM (degrees) | G1 & G2: ABD: 68 / 108, p≤0.05 | G4: ABD: 74 / 110, p≤0.05 | NR
Vad VB, 2002^165^ | G1 & G2: PT & oral medication (± steroid injection) (40) G3: Open RCR (36) G4: Arthroscopic debridement (32) 3.2 yr (2–7) | Time to maximal ROM | G1 & G2: 6.8 mo (2–16) | G3: 6.8 mo (4–16) | NR
Vad VB, 2002^165^ | G1 & G2: PT & oral medication (± steroid injection) (40) G3: Open RCR (36) G4: Arthroscopic debridement (32) 3.2 yr (2–7) | Time to maximal ROM | G1 & G2: 6.8 mo (2–16) | G4: 3.2 mo (1–8) | NR
Yamada N, 2000^197^ | G1: Steroid injection, stretching, strengthening (14) G2: Open RCR & acromioplasty (26) 4 yr (12 mo 23 yr) | JOA^*^ | 53.2 (40–65) / 71.1 (48–88), p=0.0012 | 58.8 (43–73) / 85.9 (67–100), p<0.0001 | p>0.05
Yamada N, 2000^197^ | G1: Steroid injection, stretching, strengthening (14) G2: Open RCR & acromioplasty (26) 4 yr (12 mo 23 yr) | Strength score (Manual muscle test) | ABD & ER: NR / 4- (n=3) | ABD & ER: NR / 5- (n=9) | NR

ABD = abduction; ASES = American Shoulder and Elbow scale; CI = confidence interval; CMS = Constant-Murley score; ER = external rotation; F = flexion; G = group; Insalata = L‘Insalata Shoulder Rating Questionnaire; IR = internal rotation; JOA = Japanese orthopaedic association; kg = kilogram; MCSS = mental component summary score; mo = month; MRI = magnetic resonance imaging; NR = not reported; PCSS = physical component summary score; PT = physical therapy; RCR = rotator cuff repair; ROM = range of motion; SD = standard deviation; SF-36 = Short Form-36; UCLA = University of California Los Angeles scale; yr = year;

* Subscales reported

† No group specification

‡ Calculated by UAEPC

§ Subset of patients who underwent secondary surgery following failed PT

|| Score after failed PT, prior to surgery

¶ One case was unable to undergo MRI. Two subjects had inconclusive MRI assessment (not included in the result)

Table 36 Strength of evidence for nonoperative vs. operative treatment

Technique | Number of studies; subjects (analyzed)^*^ | Outcome | Strength of evidence domains | | | | | Strength of evidence
| | | Risk of bias | Consistency | Directness | Precision | Confounding
Shock wave therapy vs. mini-open RCR | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Shock wave therapy vs. mini-open RCR | 1; 30 | Function | RCT Medium | Unknown | Direct | Imprecise | Absent | Low
Shock wave therapy vs. mini-open RCR | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Shock wave therapy vs. mini-open RCR | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Steroid injection, PT, and activity modification vs. open RCR | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Steroid injection, PT, and activity modification vs. open RCR | 1; 19 | Function | Cohort Medium | Unknown | Direct | Imprecise | Present | Low
Steroid injection, PT, and activity modification vs. open RCR | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Steroid injection, PT, and activity modification vs. open RCR | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
PT vs. open or mini- open RCR | 1; 102 | HRQL | RCT Medium | Unknown | Direct | Imprecise | Absent | Low
PT vs. open or mini- open RCR | 1; 102 | Function | RCT Medium | Unknown | Direct | Imprecise | Absent | Low
PT vs. open or mini- open RCR | 1; 50 | Cuff integrity | RCT Medium | Unknown | Direct | Imprecise | Absent | Low
PT vs. open or mini- open RCR | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
PT, oral medication, and steroid injection vs. arthroscopic debridement vs. open RCR | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
PT, oral medication, and steroid injection vs. arthroscopic debridement vs. open RCR | 1; 108 | Function | Cohort Medium | Unknown | Direct | Imprecise | Absent | Low
PT, oral medication, and steroid injection vs. arthroscopic debridement vs. open RCR | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
PT, oral medication, and steroid injection vs. arthroscopic debridement vs. open RCR | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient
Passive stretching, strengthening, and corticosteroid injection vs. open RCR with acromioplasty | 0 | HRQL | n/a | n/a | n/a | n/a | n/a | Insufficient
Passive stretching, strengthening, and corticosteroid injection vs. open RCR with acromioplasty | 1; 40 | Function | Cohort Medium | Unknown | Direct | Imprecise | Present | Low
Passive stretching, strengthening, and corticosteroid injection vs. open RCR with acromioplasty | 0 | Cuff integrity | n/a | n/a | n/a | n/a | n/a | Insufficient
Passive stretching, strengthening, and corticosteroid injection vs. open RCR with acromioplasty | 0 | Time to return to work | n/a | n/a | n/a | n/a | n/a | Insufficient

HRQL = health-related quality of life; n/a = not applicable; PT = physical therapy; RCR = rotator cuff repair

* Number analyzed if different from number studied

Shock wave therapy vs. mini-open RCR. De Carli et al.195 conducted a RCT investigating the effectiveness of extracorporeal shock wave therapy vs. mini-open RCR. Shock wave therapy was conducted using an electromagnetic generator, however no additional information on the treatment protocol was reported. All patients had full-thickness tears. A total of 30 patients were enrolled, however the sample sizes of each group and tear sizes were not reported. Patients were followed for an average of 19 months and 24 months in the shock wave and RCR groups, respectively. The difference in all scores was significant from baseline to followup. In addition, patients in the mini-open repair group showed a statistically greater improvement on the ASES and UCLA scores compared to the shock wave group.

Steroid injection, physical therapy and activity modification vs. open RCR. Lunn et al.196 conducted a prospective cohort study comparing nonoperative treatment consisting of steroid injections, physical therapy and activity modification vs. open repair. The type and injection site of the steroid, physical therapy treatment components and type of activity modification of the nonoperative group were not reported in the study. All patients had full-thickness RC tears. The mean length of followup was 4.2 years (range: 2 to 6.6). Nineteen patients were enrolled in the study (14 received nonoperative interventions, 5 received open RCR). All patients were evaluated using the CMS, range of motion (flexion, external and internal rotation), and strength. For both groups, there was a significant difference between the preoperative and postoperative CMS (p=0.009). However, the difference between the groups at endpoint was not significant (p=0.61). For both range of motion and strength, data was not presented separately by treatment group. Range of motion differed between the affected and normal side at final followup (158 vs. 176 degrees in flexion, 48 vs. 58 degrees in external rotation, and T12 vs. T7 in internal rotation). Similarly, there was a significant difference in strength between the affected and normal side at final followup (p<0.001). Cuff integrity was assessed using MRI at an average of 4.2 years. Anatomic healing was obtained in 3 cases (60 percent) in the operative group; cuff healing was not assessed in the nonoperative group.

Physical therapy (manual therapy and strengthening and stability exercises) vs. open or mini-open RCR. Moosmayer et al.66 examined the effectiveness of a physical therapy program vs. open or mini-open repair in a RCT. The physical therapy protocol consisted of manual therapy and exercises aimed at strengthening and stabilizing the shoulder muscles. Treatment session were 40 minutes and were provided on average twice weekly during the first 12 weeks, and then less frequently during the subsequent 6 to 12 weeks. The treatment goals and methods were specified before the study, however they were provided in a non-standardized manner according to the examination findings and treatment progression. One hundred and three patients with small or medium-sized full-thickness tears were randomly assigned to physical therapy (51 patients) or open/mini-open repair (52 patients). All but one patient in the repair group were followed for 12 months and included in the analysis. In the physical therapy group, 9 patients showed inadequate improvement from baseline after 15 sessions, and underwent secondary surgery. Their final assessment after the 15 sessions was carried forward for the 6 and 12 month analyses. There was no difference between physical therapy and RCR on the SF-36 physical or mental component summary scores, however a significant difference was found for the ASES (p<0.0005) and CMS (p=0.002), in favour of the surgical repair group. Cuff integrity was measured using MRI in the operative group only, where 38 of 50 patients were found to have an intact rotator cuff.

Physical therapy, oral medication and steroid injection vs. open RCR vs. arthroscopic debridement. Vad et al.165 conducted a retrospective cohort study comparing four treatment arms: physical therapy and oral medication alone and with the addition of steroid injection, open RCR and arthroscopic debridement. The physical therapy treatment components, type of oral medication and steroid, and the steroid injection site were not specified in the study. One hundred and eight patients with massive full-thickness RC tears were enrolled in the study (28 received nonoperative treatment without steroid, 12 received nonoperative treatment with steroid, 36 received open RCR and 32 received debridement). The study reported combined outcome data for the two nonoperative treatment arms. All patients were followed for a minimum of 2 years; the mean followup duration was 3.2 years. Patients were evaluated using the Insalata shoulder rating questionnaire, range of motion (abduction), and time to maximum range of motion. For all groups, there were significant differences in the Insalata score and range of motion from preoperative to postoperative scores (p≤0.05). In addition, there were significant between-group differences in the Insalata score at final followup, favoring surgery over nonoperative treatment. The time to maximal range of motion was significantly different between the groups, with 6.8 months for the nonoperative and open RCR groups, and 3.2 months for the arthroscopic debridement group.

Steroid injection, stretching and strengthening vs. open RCR. Yamada et al.197 conducted a retrospective cohort study comparing nonoperative treatment vs. open repair with acromioplasty. Patients in the nonoperative groups received a mixture of 1% lidocaine (4 mL) and dexamethasone sodium phosphate (2 mg) injected into the subacromial bursa once or twice per week, as well as heat treatments, passive stretching and strengthening exercises. Forty patients with massive tears enrolled in the study (14 received the nonoperative treatment, 26 received surgical repair). All patients were followed for a mean length of 4 years (12 months to 23 years). The JOA shoulder scale and strength score were used to evaluate patients. There was significant improvement in the JOA score for both the nonoperative treatment group (p=0.0012) and the operative group (p<0.0001). However, the difference in the JOA score between the groups at final followup was not significant (p>0.05). At study endpoint, muscle strength was greater in the operative group than the nonoperative group; however the statistical significance of this difference was not reported.

Separate meta-analyses were conducted for the two trials and three cohort studies comparing the effects of nonoperative treatment vs. surgical repair on functional outcome measures (Figure 31). The scales used to measure function included the ASES,66 CMS,196 Insalata,165 JOA,197 and the UCLA.195 Both of the trials significantly favoured repair over nonoperative treatments for functional outcomes. For the cohort studies, the pooled estimate of change in function shows no significant difference between groups, although the surgical repair is favored (SMD=−1.34; 95% CI, −2.95, 0.27). There was substantial heterogeneity between the three studies (p<0.0001, I2=92 percent), which may be attributed to differences in the nonoperative treatment components and the characteristics of the patients enrolled in each study.

Two cohort studies196,197 provided data for meta-analysis for the effects of nonoperative treatment vs. surgical repair on pain (Figure 32). The pain subscales of the CMS196 and JOA197 scales were used in this analysis. Baseline to followup change scores were compared between groups. The pooled analysis showed no statistically significant difference between the two treatments for pain (SMD=0.81; 95% CI, −1.26 to 2.88). Heterogeneity between the studies was substantial (p=0.001, I2=90).

### Question 5. Complications

Summary. Overall, 85 of the 137 studies included in this review reported data on complications across all interventions. Sixty-four studies reported at least one event of the 34 different complications identified, while 21 studies reported no complications and 52 studies did not report any data on complications. In general, the rates of complications were low and the majority of complications were not deemed to be clinically important or were reported only in a few studies. Throughout, “rate” refers to the number of patients experiencing complications during the study period. Study lengths vary, so no standardized time period is used. A priori, we identified the following complications to be the most clinically important:

- Retears: This complication was reported in 14 studies. Among the 9 studies examining operative approaches, the rates of retear were generally low (≤0.10). One retrospective cohort study113 investigating operative augmentation using McLaughlin procedure vs. patch graft found retear rates of 0 vs. 0.18. Three studies examining postoperative rehabilitation reported low rates (≤0.14). In addition, retears due to technical failures were reported in 16 studies. In 12 studies investigating operative approaches, the reported rates of technical failure were low (≤0.07). Rates for technical failure for a variety of operative techniques ranged from 0 to 0.33, and for one operative augmentation study67 the rate was 0.03.
- Infection: 32 studies reported data on infection. Among 25 studies that examined operative approaches, the rate of infection was low with the majority of studies reporting no infections. Studies of operative techniques and augmentations generally reported low rates of infection (≤0.05). Three studies examining postoperative rehabilitation reported low rates of infection, except in one study179 for a progressive rehabilitation program reporting a rate of 0.29.
- Stiffness: 24 studies provided data on stiffness following treatment. The rates were low (≤0.08) among 20 studies examining operative approaches. Higher rates of postoperative stiffness were observed for mini-open RCRs with two of the six studies reporting rates of 0.14^157^ and 0.17.^171^ Likewise, two of the 10 studies examining arthroscopic RCR reported rates of 0.08^80^ and 0.11.^171^ One study81 examining a single vs. double-row operative technique and one109 on augmentation both reported low rates of postoperative stiffness, with 0.06 and 0, respectively. Similarly, two nonoperative studies reported low rates of 0.04^190^ and 0.07.^186^
- Reflex sympathetic dystrophy: In general the rates of reflex sympathetic dystrophy were low (≤0.02) across the seven studies examining operative approaches; however, higher rates were observed in a BA study122 of arthroscopic RCR (0.12) and a retrospective cohort study63 of arthroscopic debridement with tenotomy (0.13). One study180 evaluating postoperative rehabilitation reported one case of reflex sympathetic dystrophy among the 15 patients studied.
- Neurological injury: The rates of postoperative neurological injury were low (≤0.06) in 12 studies examining operative approaches, techniques or augmentations.

Results by complication. Of the 137 studies included in this review, 85 studies reported on 34 different complications for nonoperative and operative interventions (see tables below); 52 studies (eight trials,71,102,105,133,143,178,185,195 five prospective cohort studies,72,85,148,177,196 nine retrospective cohort studies,87,106,125,154,165,172,181,183,197 18 BA studies, 60,69,79,89,90,100,104,115,116,123,142,160,166,168,175,187,192,193 eleven cohort studies providing BA data,62,86,126,128,135,141,144,149,150,188,191 and one case-control study164) did not report any data on complications (Table 61). The tables report complications for study arms separately. The majority of complications were reported for operative studies; only two studies186,190 reported complications associated with nonoperative treatments, one study reported complications with nonoperative vs. operative treatments,66 while four postoperative rehabilitation studies179,180,182,184 reported complications. Complication rates for studies focusing on postoperative rehabilitation may be attributable to either the preceding surgery or the rehabilitation components.

Table 61 Complications not reported

Intervention | Author, year Category Design
Open RCR | Caniggia 1995^79^ Operative approach BA
Open RCR | Cools 2006^86^ Operative approach Cohort – BA data
Open RCR | Iannotti 1996^60^ Operative approach BA
Open RCR | Kirschenbaum 1993^115^ Operative approach BA
Open RCR | Mallon 2004^128^ Operative approach Cohort – BA data
Open RCR | Misamore 1995^135^ Operative approach Cohort – BA data
Open RCR | Trenerry 2005^164^ Operative approach Case control – BA data
Mini-open RCR | Baysal 2005^69^ Operative approach BA
Open or mini-open RCR | Klepps 2004^116^ Operative BA
Open or mini-open RCR | Vitale 2007^168^ Operative approach BA
Open or mini-open or arthroscopic RCR | Gladstone 2007^104^ Operative approach Cohort – BA data
Open or mini-open or arthroscopic RCR | Tashjian 2006^160^ Operative approach BA
Open or arthroscopic RCR | Davidson 2000^89^ Operative approach BA
Open or arthroscopic RCR | Oh 2008^144^ Operative approach Cohort – BA data
Open vs. mini-open RCR | Hata 2004^106^ Operative approach Retrospective cohort1
Open vs. arthroscopic RCR | Costouros 2006^87^ Operative approach Retrospective cohort
Open or mini-open vs. arthroscopic RCR | Bishop 2006^72^ Operative approach Prospective cohort
Mini-open vs. arthroscopic RCR | Colegate-Stone 2009^85^ Operative approach Prospective cohort
Mini-open vs. arthroscopic RCR | Liem 2007^125^ Operative approach Retrospective cohort
Mini-open vs. arthroscopic RCR | Pearsall 2007^148^ Operative approach Prospective cohort
Mini-open vs. arthroscopic RCR | Sauerbrey 2005^154^ Operative approach Retrospective cohort
Arthroscopic RCR | Bennett 2003^62^ Operative approach Cohort – BA data
Arthroscopic RCR | DeFranco 2007^90^ Operative BA
Arthroscopic RCR | Levy 2008^123^ Operative BA
Arthroscopic RCR | Nho 2009^142^ Operative BA
Double-row vs. single row arthroscopic RCR | Grasso 2009^105^ Operative technique RCT
Side-to-side repair vs. tendon to bone repair | Bigoni 2009^71^ Operative technique RCT
Arthroscopic RCR: staple fixation vs. side-to-side suture | Wilson 2002^172^ Operative technique Retrospective cohort
Mini-open RCR vs. shock wave therapy | De Carli 2006^195^ Non-operative vs. operative RCT
Rehab as inpatient vs. outpatient | Delbrouck 2004^177^ Postoperative rehabilitation Prospective cohort
Inpatient rehabilitation centre vs. private practice specializing in ‘CGE’ | Marc 2009^181^ Postoperative rehabilitation Retrospective cohort
Inpatient rehabilitation centre vs. private practice specializing in ‘CGE’ | Gartsman 1998^100^ Operative approach BA
Inpatient rehabilitation centre vs. private practice specializing in ‘CGE’ | Nam 2008^141^ Operative approach Cohort – BA data
Inpatient rehabilitation centre vs. private practice specializing in ‘CGE’ | Porcellini 2006^150^ Operative approach Cohort – BA data
Inpatient rehabilitation centre vs. private practice specializing in ‘CGE’ | Pillay 1994^149^ Operative approach Cohort – BA data
Open RCR vs. arthroscopic debridement | Ogilvie-Harris 1993^143^ Operative approach CCT
Arthroscopic debridement only | Vaz 2000^166^ Operative approach BA
Arthroscopic RCR & acromioplasty vs. arthroscopic RCR alone | Gartsman 2004^102^ Operative approach RCT
Arthroscopic RCR & acromioplasty vs. arthroscopic RCR alone | Milano 2007^133^ Operative approach RCT
Arthroscopic decompression | Lim 2005^126^ Operative approach Cohort – BA data
Rehabilitation vs. no rehabilitation | Leroux 1993^191^ Post-operative rehabilitation Retrospective cohort
Individualized PT & home exercise program vs. home exercise program | Hayes 2004^178^ Post-operative rehabilitation RCT
Home exercise: Videotape-based vs. PT instruction | Roddey 2002^185^ Post-operative rehabilitation RCT
Standardized vs. non-standardized PT program | Milroy 2008^183^ Post-operative rehabilitation Retrospective cohort
Postoperative rehabilitation | Boissonnault 2007^175^ Post-operative rehabilitation BA
Nonoperative treatment | Hawkins 1995^187^ Nonoperative approach BA (Exercise protocol)
Nonoperative treatment | Heers 2005^188^ Nonoperative approach Cohort – BA data (Home exercise program)
Nonoperative treatment | Levy 2008^192^ Nonoperative approach BA (Anterior deltoid rehabilitation program)
Nonoperative treatment | Scheuermann 1991^193^ Nonoperative BA (Early functional PT and active shoulder support)
Nonoperative treatment vs. RCR | Lunn 2008^196^ Operative vs. nonoperative Prospective cohort
Nonoperative treatment vs. RCR | Vad 2002^165^ Operative vs. nonoperative Retrospective cohort
Nonoperative treatment vs. RCR | Yamada 2000^197^ Operative vs. nonoperative Retrospective cohort

BA = before-and-after; CCT = controlled clinical trial; PT = physical therapy; RCR = rotator cuff repair; RCT = randomized controlled trial

Twenty-one studies (seven trials,78,96–98,163,176,194 one prospective cohort,159 two retrospective cohorts,132,138 and 11 BA studies84,91,95,99,111,121,131,158,162,174,189) reported that no complications occurred during the course of the study (Table 60). The remaining 63 studies reported at least one event in the course of a nonoperative, operative, or postoperative rehabilitation treatment. Of these 63, twelve were trials: seven73,81,109,114,117,136,137 that compared operative interventions, four179,180,182,184 that compared postoperative rehabilitation, and one that compared nonoperative and operative interventions.66 Twenty-one studies used a cohort design, 63,64,68,75,77,88,94,112,113,118,119,129,134,139,140,147,157,167,170,171,173 all of which compared operative interventions. Thirty-one studies used a BA design: 29 studies,65,67,70,74,76,80,82,83,92,93,101,103,107,108,110,120,122,124,127,130,145,146,151–153,155,156,161,169 examined operative interventions and two186,190 examined nonoperative interventions. No BA studies provided data on complications for postoperative rehabilitation.

Table 60 No complications

Intervention | Author, year Category Design
Open RCR | McCallister 2005^131^ Operative approach BA
Arthroscopic RCR | Cole 2007^84^ Operative approach BA – Report zeros
Arthroscopic RCR | Lafosse 2007^121^ Operative approach BA
Arthroscopic RCR | Sugaya 2007^158^ Operative approach BA
Arthroscopic RCR | Deutsch 2007^91^ Operative approach BA
Arthroscopic RCR | Ide 2005^111^ Operative approach BA
Arthroscopic RCR | Tauro 2006^162^ Operative approach Cohort – BA data
Open debridement & tuberplasty | Fenlin 2002^95^ Operative approach BA
Arthroscopic RCR & SLAP repair vs. arthroscopic RCR & biceps tenotomy | Franceschi 2008^96^ Operative approach RCT
RCR & tenodesis with detachment vs. RCR & tenodesis without detachment | Franceschi 2007b97 Operative approach RCT
Classic open acromioplasty vs. modified open acromioplasty | Torrens 2003^163^ Operative approach CCT
Complete open RCR vs. partial open RCR vs. debridement | Moser 2007^138^ Operative approach Retrospective cohort
Open RCR & augmentation | Zumstein 2008^174^ Operative augmentation BA
Open RCR & augmentation | Fuchs 2006^99^ Operative augmentation BA
Double-row vs. single-row arthroscopic RCR | Burks RT, 2009^78^ Operative technique RCT
Double-row vs. single-row arthroscopic RCR | Franceschi 2007a98 Operative technique RCT
Double-row vs. single-row arthroscopic RCR | Sugaya 2005^159^ Operative technique Prospective cohort
Ultrasonic suture welding vs. hand-tied knots (mini-open RCR) | McIntyre 2006^132^ Operative technique Retrospective cohort
Land-based & Aquatic therapy program vs. land-based program | Brady 2008^176^ Post-operative rehabilitation CCT
Sodium hyaluraonate vs. dexamethasone | Shibata 2001^194^ Nonoperative approach RCT
Pulsed radiofrequency ablation | Kane 2008^189^ Nonoperative approach BA

BA = before-and-after; CCT = controlled clinical trial; RCR = rotator cuff repair; RCT = randomized controlled trial; SLAP = superior labrum from anterior to posterior

Retears. Fourteen studies (Table 37) reported postoperative retears (three trials,179,182,184 five cohort studies,77,112,113,157,173 six uncontrolled studies70,83,127,151–153). These studies used clinical evaluation or imaging to identify the presence of retears in patients who were unsatisfied with their postoperative outcome. It should be noted that not all retears are symptomatic (e.g., associated with pain, stiffness, reduced function), theref ore some retears may have been undetected in patients who were satisfied with their clinical outcome. Studies which systematically examined all patients using imaging to investigate what proportion had an intact cuff are reported under the key outcome “tendon integrity” above. Overall, the rates of retears from 10 studies that examined operative approach were consistent and rates ranged from 0 to 0.10. Rates of retears for McLaughlin procedure, patch graft113 and platelet-rich plasma augmentation152 with arthroscopic repair were 0, 0.18, and 0.07, respectively. Studies examining physical therapy alone182,184 and physical therapy with continuous passive motion184 reported rates ranging from 0 to 0.05, while one study179 reported a rate of 0.14 for a traditional postoperative rehabilitation program and no events for a progressive rehabilitation program.

Table 37 Re-tear

Intervention | Author, year Category Design | Patients evaluation; Evaluation criteria (imaging/clinical) | Events | Sample size | Rate (95% CI)
Operative
Open RCR | Cofield 2001^83^ Operative approach BA | Unsatisfied; Clinical | 3^‡^ | 105 | 0.03 (0.01–0.08)
Open RCR | Prasad 2005^151^ Operative approach BA | Unsatisfied; Clinical | 1 | 40 | 0.03 (0.004–0.13)
Open RCR | Rokito 1999^153^ Operative approach BA | Unsatisfied; Clinical | 3 | 30 | 0.1 (0.03–0.26)
Mini-open RCR | Severud 2003^157^ Operative approach Retrospective cohort | Unsatisfied; Clinical | 1 | 29 | 0.03 (0.01–0.17)
Mini-open RCR | Youm 2005^173^ Operative approach Retrospective cohort | Unsatisfied; Clinical | 3 | 42 | 0.07 (0.02–0.19)
Arthroscopic RCR | Bennett 2003^70^ Operative approach BA | Unsatisfied; Clinical | 1 | 24 | 0.04 (0.01–0.20)
Arthroscopic RCR | Buess 2005^77^ Operative approach Prospective cohort | Unsatisfied; Clinical | 2^§^ | 66 | 0.03 (0.008–0.10)
Arthroscopic RCR | Ide 2005^112^ Operative approach Prospective cohort | Unsatisfied; MRI | 1 | 50 | 0.02 (0.003–0.10)
Arthroscopic RCR | Severud 2003^157^ Operative approach Retrospective cohort | Unsatisfied; Clinical | 0 | 35 | 0 (0.00–0.07)
Arthroscopic RCR | Youm 2005^173^ Operative approach Retrospective cohort | Unsatisfied; Clinical | 1 | 42 | 0.02 (0.004–0.12)
Open or mini-open RCR | Buess 2005^77^ Operative approach Prospective cohort | Unsatisfied; Clinical | 0 | 30 | 0 (0.00–0.08)
Stabilization of LHB & open RCR | Maier 2007^127^ Operative approach BA | Unsatisfied; Clinical | 2 | 21 | 0.10 (0.03–0.29)
McLaughlin procedure RCR | Ito 2003^113^ Operative augmentation Retrospective cohort | Unsatisfied; Clinical | 0 | 13 | 0 (0.00–0.17)
Patch graft RCR | Ito 2003^113^ Operative augmentation Retrospective cohort | Unsatisfied; Clinical | 3 | 17 | 0.18 (0.06–0.41)
Arthroscopic RCR & platelet-rich plasma augmentation | Randelli 2008^152^ Operative augmentation BA | Unsatisfied; Clinical | 1^*^ | 14 | 0.07 (0.01–0.3)
Postoperative Rehabilitation
PT alone | Michael 2005^182^ Post-operative rehabilitation RCT | Unsatisfied; Clinical | 1 | 21 | 0.05 (0.01–0.23)
Continuous passive motion & PT | Michael 2005^182^ Post-operative rehabilitation RCT | Unsatisfied; Clinical | 0 | 34 | 0 (0.00–0.07)
Continuous passive motion & PT program vs. PT alone | Raab 1996^184^ Post-operative rehabilitation RCT | Unsatisfied; Clinical | 1^†^ | 26 | 0.04 (0.007–0.19)
Progressive group | Klintberg 2009^179^ Post-operative rehabilitation RCT | Unsatisfied; Clinical | 0 | 7 | 0 (0.00–0.28)
Traditional group | Klintberg 2009^179^ Post-operative rehabilitation RCT | Unsatisfied; Clinical | 1 | 7 | 0.14 (0.03–0.51)

BA = before-and-after; CI = confidence interval; LHB = long head of biceps; MRI = magnetic resonance imaging; PT = physical therapy; RCR = rotator cuff repair; RCT = randomized controlled trial

* Re-tear due to injury. Patient unavailable for last followup and sample size represents the number of patients enrolled.

† No group specified.

‡ Retear due to injury (2) and aggressive PT (1)

§ One patient experienced retear and stiffness

Technical failure. Sixteen studies reported failure of anchors or other surgical constructs (seven cohort studies88,112,118,134,147,157,167 and nine uncontrolled studies67,74,82,92,110,122,146,161,169) (Table 38). Overall, the rates of technical failure from twelve studies that examined operative approach ranged from 0 to 0.07, with only one study82 reporting a rate higher than 0.05. Rates for technical failure in 4 studies for a variety of operative techniques were provided and ranged from 0 to 0.33. One operative augmentation study had a rate of 0.03.

Table 38 Technical failure

Intervention | Author, year Category Design | Events | Sample size | Rate (95% CI)
Operative
Open RCR | Ide 2005^112^ Operative approach Prospective cohort | 0 | 50 | 0 (0.00–0.05)
Open RCR | Millar NL, 2009^134^ Operative approach/technique Retrospective cohort | 0 | 20 | 0 (0.00–0.12)
Mini-open RCR | Severud 2003^157^ Operative approach Retrospective cohort | 0 | 29 | 0 (0.00–0.09)
Mini-open RCR | Verma 2006^167^ Operative approach Retrospective cohort | 0 | 33 | 0 (0.00–0.08)
Arthroscopic RCR | Boileau 2005^74^ Operative approach BA | 0 | 65 | 0 (0.00–0.04)
Arthroscopic RCR | Deutsch 2008^92^ Operative approach Cohort – BA data | 2 | 39 | 0.05 (0.01–0.17)
Arthroscopic RCR | Ide 2007^110^ Operative approach BA | 0 | 20 | 0 (0.00–0.12)
Arthroscopic RCR | Ide 2005^112^ Operative approach Prospective cohort | 0 | 50 | 0 (0.00–0.05)
Arthroscopic RCR | Lafosse 2007^122^ Operative approach BA | 0 | 17 | 0 (0.00–0.14)
Arthroscopic RCR | Park 2004^146^ Operative approach Cohort – BA data | 0 | 42 | 0 (0.00–0.06)
Arthroscopic RCR | Severud 2003^157^ Operative approach Retrospective cohort | 0 | 35 | 0 (0.00–0.07)
Arthroscopic RCR | Tauro 2004^161^ Operative approach BA | 1 | 42 | 0.02 (0.004–0.12)
Arthroscopic RCR | Verma 2006^167^ Operative approach Retrospective cohort | 1 | 38 | 0.03 (0.005–0.13)
Arthroscopic RCR | Waibl 2005^169^ Operative approach BA | 1 | 22 | 0.05 (0.008–0.22)
Arthroscopic RCR & biceps tenodesis | Checchia 2005^82^ Operative approach BA | 1 | 15 | 0.07 (0.01–0.30)
Single-row fixation | Park 2008^147^ Operative technique Prospective cohort | 1 | 40 | 0.03 (0.004–0.13)
Double-row fixation | Park 2008^147^ Operative technique Prospective cohort | 1 | 38 | 0.03 (0.005–0.13)
Simple stitch | Ko 2008^118^ Operative technique Prospective cohort | 9 | 39 | 0.23 (0.005–0.13)
Modified mattress locking stitch | Ko 2008118 Operative technique Prospective cohort | 6 | 36 | 0.17 (0.08–0.32)
Mitek metal suture anchor (open RCR) | Cummins 2003^88^ Operative technique Prospective cohort | 0 | 18 | 0 (0.00–0.13)
Headed bio-corkscrews (open RCR) | Cummins 2003^88^ Operative technique Prospective cohort | 3 | 9 | 0.33 (0.12–0.65)
Arthroscopic knotted | Millar NL, 2009^134^ Operative approach/technique Retrospective cohort | 1 | 29 | 0.03 (0.006–0.17)
Arthroscopic knotless | Millar NL, 2009^134^ Operative approach/technique Retrospective cohort | 0 | 38 | 0 (0.00–0.07)
Mattress suture vs. transosseus suture (arthroscopic RCR) | Matis 2006^129^ Operative technique Prospective cohort | 1^*^ | 90 | 0.01 (0.002–0.06)
Open RCR & augmentation | Audenaert 2006^67^ Operative augmentation BA | 1 | 39 | 0.03 (0.005–0.13)

BA = before-and-after; CI = confidence interval; RCR = rotator cuff repair

* No group specification

Infection. Thirty-two studies reported data on infection (five trials,73,136,179,180,182 eleven cohort studies, 63,68,75,77,88,94,112,113,119,147,157 and 16 uncontrolled studies65,74,80,82,83,101,103,108,110,122,124,130,145,146,155,161) (Table 39). Overall, the rates of infection from 25 studies that examined operative approach ranged from 0 to 0.06 with many studies reporting no infections. Rates of infection for various operative techniques and augmentations were provided and ranged from 0 to 0.05. Three RCTs179,180,182 investigating postoperative rehabilitation provided data on infection rates but the events are likely related to surgery and may not necessarily be attributed to the rehabilitation program.

Table 39 Infection

Intervention | Author, year Category Design | Events | Sample size | Rate (95% CI)
Operative
Open RCR | Baker 1995^68^ Operative approach Retrospective cohort | 1 | 20 | 0.05 (0.01–0.24)
Open RCR | Cofield 2001^83^ Operative approach BA | 2 | 105 | 0.02 (0.005–0.07)
Open RCR | Gazielly 1994^103^ Operative approach BA | 0 | 100 | 0 (0.00–0.03)
Open RCR | Hsu 2007^108^ Operative approach BA | 0 | 47 | 0 (0.00–0.05)
Open RCR | Ide 2005^112^ Operative approach Prospective cohort | 0 | 50 | 0 (0.00–0.05)
Open RCR | Mohtadi 2008^136^ Operative approach RCT | 0 | 29 | 0 (0.00–0.09)
Open RCR | Pai 2001^145^ Operative approach BA | 2 | 58 | 0.03 (0.01–0.10)
Mini-open RCR | Baker 1995^68^ Operative approach Retrospective cohort | 1 | 17 | 0.06 (0.01–0.27)
Mini-open RCR | Kose 2008^119^ Operative approach Retrospective cohort | 1 | 25 | 0.04 (0.007–0.20)
Mini-open RCR | Mohtadi 2008^136^ Operative approach RCT | 0 | 31 | 0 (0.00–0.08)
Mini-open RCR | Severud 2003^157^ Operative approach Retrospective cohort | 0 | 29 | 0 (0.00–0.09)
Arthroscopic RCR | Boileau 2005^74^ Operative approach BA | 0 | 65 | 0 (0.00–0.04)
Arthroscopic RCR | Buess 2005^77^ Operative approach Prospective cohort | 0 | 66 | 0 (0.00–0.04)
Arthroscopic RCR | Charousset 2008^80^ Operative approach BA | 0 | 104 | 0 (0.00–0.03)
Arthroscopic RCR | Ide 2007^110^ Operative approach BA | 0 | 20 | 0 (0.00–0.12)
Arthroscopic RCR | Ide 2005^112^ Operative approach Prospective cohort | 0 | 50 | 0 (0.00–0.05)
Arthroscopic RCR | Kose 2008^119^ Operative approach Retrospective cohort | 0 | 25 | 0 (0.00–0.10)
Arthroscopic RCR | Lafosse 2007^122^ Operative approach BA | 0 | 17 | 0 (0.00–0.14)
Arthroscopic RCR | Lichtenberg 2006^124^ Operative approach BA | 0 | 53 | 0 (0.00–0.05)
Arthroscopic RCR | McBirnie 2005^130^ Operative approach BA | 1 | 53 | 0.02 (0.003–0.10)
Arthroscopic RCR | Severud 2003^157^ Operative approach Retrospective cohort | 0 | 35 | 0 (0.005–0.15)
Arthroscopic RCR | Park 2004^146^ Operative approach Cohort – BA data | 0 | 42 | 0 (0.00–0.06)
Arthroscopic RCR | Tauro 2004^161^ Operative approach BA | 1 | 42 | 0.02 (0.004–0.12)
Open or mini-open RCR | Buess 2005^77^ Operative approach Prospective cohort | 1 | 30 | 0.03 (0.006–0.17)
Arthroscopic RCR & biceps tenodesis | Checchia 2005^82^ Operative approach BA | 0 | 15 | 0 (0.00–0.15)
Open debridement & acromioplasty | Gartsman 1997^101^ Operative approach BA | 1 | 33 | 0.03 (0.005–0.15)
Arthroscopic debridement | Klinger 2005^65^ Operative approach BA | 0 | 33 | 0 (0.00–0.08)
Arthroscopic debridement with tenotomy | Klinger 2005^63^ Operative approach Retrospective cohort | 0 | 24 | 0 (0.00–0.10)
Arthroscopic debridement without tenotomy | Klinger 2005^63^ Operative approach Retrospective cohort | 0 | 17 | 0 (0.00–0.14)
Biceps tenotomy vs. tenodesis | Boileau 2007^75^ Operative approach Retrospective cohort | 1^†^ | 72 | 0.01 (0.002–0.07)
Watertight anatomical repair | Favard 2009^94^ Operative approach Retrospective cohort | 2 | 103 | 0.02 (0.005–0.07)
Palliative treatment (partial repair or LHB tenotomy) | Favard 2009^94^ Operative approach Retrospective cohort | 1 | 89 | 0.01 (0.002–0.06)
Double-row fixation | Park 2008^147^ Operative technique Prospective cohort | 0 | 38 | 0 (0.00–0.07)
Single-row fixation | Park 2008^147^ Operative technique Prospective cohort | 2 | 40 | 0.05 (0.01–0.17)
Mason-Allen technique with non- absorbable sutures | Boehm 2005^73^ Operative technique RCT | 2 | 49 | 0.04 (0.01–0.14)
Kessler technique with absorbable sutures | Boehm 2005^73^ Operative technique RCT | 1 | 44 | 0.02 (0.004–0.12)
Open RCR & augmentation | Scheibel 2007^155^ Operative augmentation BA | 1 | 23^*^ | 0.04 (0.008–0.21)
McLaughlin procedure RCR | Ito 2003^113^ Operative augmentation Retrospective cohort | 0 | 17 | 0 (0.00–0.14)
Patch graft RCR | Ito 2003^113^ Operative augmentation Retrospective cohort | 0 | 13 | 0 (0.00–0.17)
Postoperative Rehabilitation
Continuous passive motion & PT program | LaStayo 1998^180^ Post-operative rehabilitation RCT | 1 | 17 | 0.06 (0.01–0.27)
Continuous passive motion & PT program | Michael 2005^182^ Post-operative rehabilitation RCT | 2 | 34 | 0.06 (0.02–0.19)
PT alone | LaStayo 1998^180^ Post-operative rehabilitation RCT | 0 | 15 | 0 (0.00–0.15)
PT alone | Michael 2005^182^ Post-operative rehabilitation RCT | 1 | 21 | 0.05 (0.01–0.23)
Progressive group | Klintberg, 2009^179^ Post-operative rehabilitation RCT | 2 | 7 | 0.29 (0.08–0.64)
Traditional group | Klintberg, 2009^179^ Post-operative rehabilitatio n RCT | 0 | 7 | 0 (0.00–0.28)

BA = before-and-after; CI = confidence interval; LHB = long head of biceps; PT = physical therapy; RCR = rotator cuff repair; RCT = randomized controlled trial

* Sample size represents the number of participants enrolled in the study because the patient with the complication was excluded from the analysis.

† No group specification

Stiffness. Twenty-four studies provided data on stiffness following treatment (four trials,81,109,136,137 seven cohort studies,77,94,112,157,167,171,173 three cohort studies with BA data,92,107,146 and ten BA studies65,74,76,80,110,124,145,151,186,190) (Table 40). Overall, the rates of postoperative stiffness from 21 studies that examined operative approach ranged from 0 to 0.17 with six studies reporting no events.109,110,112,124,136,146 Rates for operative techniques and nonoperative treatment ranged from 0 to 0.6 and 0.04 to 0.07, respectively. One study109 examining operative augmentation reported no events.

Table 40 Stiffness

Intervention | Author, year Category Design | Events | Sample size | Rate (95% CI)
Operative
Open RCR | Iannotti 2006^109^ Operative augmentation RCT | 0 | 15 | 0 (0.00–0.15)
Open RCR | Ide 2005^112^ Operative approach Prospective cohort | 0 | 50 | 0 (0.00–0.05)
Open RCR | Mohtadi 2008^136^ Operative approach RCT | 0 | 29 | 0 (0.00–0.09)
Open RCR | Montgomery 1994^137^ Operative approach CCT | 1 | 50 | 0.02 (0.004–0.11)
Open RCR | Pai 2001^145^ Operative approach BA | 1 | 58 | 0.02 (0.003–0.09)
Open RCR | Prasad 2005^151^ Operative approach BA | 1 | 40 | 0.03 (0.004–0.13)
Mini-open RCR | Boszotta 2004^76^ Operative approach BA | 1 | 84 | 0.01 (0.002–0.06)
Mini-open RCR | Mohtadi 2008^136^ Operative approach RCT | 0 | 31 | 0 (0.00–0.08)
Mini-open RCR | Severud 2003^157^ Operative approach Retrospective cohort | 4 | 29 | 0.14 (0.06–0.31)
Mini-open RCR | Verma 2006^167^ Operative approach Retrospective cohort | 0 | 33 | 0 (0.00–0.08)
Mini-open RCR | Warner 2005^171^ Operative approach Retrospective cohort | 2 | 12 | 0.17 (0.05–0.45)
Mini-open RCR | Youm 2005^173^ Operative approach Retrospective cohort | 0 | 42 | 0 (0.00–0.06)
Open or mini-open RCR | Buess 2005^77^ Operative approach Prospective cohort | 1 | 30 | 0.03 (0.006–0.17)
Arthroscopic RCR | Boileau 2005^74^ Operative approach BA | 1 | 65 | 0.02 (0.003–0.08)
Arthroscopic RCR | Buess 2005^77^ Operative approach Prospective cohort | 4^*^ | 66 | 0.06 (0.02–0.15)
Arthroscopic RCR | Charousset 2008^80^ Operative approach BA | 8 | 104 | 0.08 (0.04–0.14)
Arthroscopic RCR | Deutsch 2008^92^ Operative approach Cohort – BA data | 1 | 39 | 0.03 (0.005–0.13)
Arthroscopic RCR | Ide 2007^110^ Operative approach BA | 0 | 20 | 0 (0.00–0.12)
Arthroscopic RCR | Ide 2005^112^ Operative approach Prospective cohort | 0 | 50 | 0 (0.00–0.05)
Arthroscopic RCR | Lichtenberg 2006^124^ Operative approach BA | 0 | 53 | 0 (0.00–0.05)
Arthroscopic RCR | Park 2004^146^ Operative approach Cohort – BA data | 0 | 42 | 0 (0.00–0.06)
Arthroscopic RCR | Severud 2003^157^ Operative approach Retrospective cohort | 0 | 35 | 0 (0.00–0.07)
Arthroscopic RCR | Verma 2006^167^ Operative approach Retrospective cohort | 1 | 38 | 0.03 (0.005–0.13)
Arthroscopic RCR | Warner 2005^171^ Operative approach Retrospective cohort | 1 | 9 | 0.11 (0.02–0.44)
Arthroscopic RCR | Youm 2005^173^ Operative approach Retrospective cohort | 2 | 42 | 0.05 (0.1–0.16)
Combination approach | Henn 2008^107^ Operative approach Cohort – BA data | 2 | 125 | 0.02 (0.004–0.06)
Arthroscopic debridement | Klinger 2005^65^ Operative approach BA | 1 | 33 | 0.03 (0.005–0.15)
Arthroscopic debridement | Montgomery 1994^137^ Operative approach CCT | 1 | 38 | 0.03 (0.005–0.13)
Watertight anatomical repair | Favard 2009^94^ Operative approach Retrospective cohort | 7 | 103 | 0.07 (0.03–0.13)
Palliative treatment (partial repair or LHB tenotomy) | Favard 2009^94^ Operative approach Retrospective cohort | 1 | 89 | 0.01 (0.002–0.06)
Single-row arthroscopic RCR | Charousset 2007^81^ Operative technique RCT | 2 | 33 | 0.06 (0.02–0.20)
Double-row arthroscopic RCR | Charousset 2007^81^ Operative technique RCT | 0 | 28 | 0 (0.00–0.09)
Open RCR & porcine augmentation | Iannotti 2006^109^ Operative augmentation RCT | 0 | 15 | 0 (0.00–0.15)
Nonoperative
Nonoperative treatment (analgesic, NSAID, steroid injection, reeducation program) | Koubaa 2006^190^ Nonoperative BA | 1 | 24 | 0.04 (0.007–0.20)
Nonoperative treatment (analgesic, NSAID, steroid injection, reeducation program) | Ghroubi 2008^186^ Nonoperative BA | 4 | 59 | 0.07 (0.03–0.16)

BA = before-and-after; CCT = controlled clinical trial; CI = confidence interval; LHB = long head of biceps; NSAID = non-steroidal anti-inflammatory drug; RCR = rotator cuff repair; RCT = randomized controlled trial

* One patient experienced stiffness and retear

Reflex sympathetic dystrophy. Eight studies (one trial,180 two cohort studies,63,75 and five uncontrolled studies103,108,122,130,145) provided data on reflex sympathetic dystrophy (Table 41). Overall, the rates of dystrophy from seven studies that examined operative approach ranged from 0 to 0.13. One study180 compared physical therapy alone with continuous passive motion and physical therapy and reported rates of 0.7 and 0, respectively.

Table 41 Reflex sympathetic dystrophy

Intervention | Author, year Category Design | Events | Sample size | Rate (95% CI)
Operative
Open RCR | Hsu 2007^108^ Operative approach BA | 1 | 47 | 0.02 (0.004–0.11)
Open RCR | Gazielly 1994^103^ Operative approach BA | 2 | 100 | 0.02 (0.006–0.07)
Open RCR | Pai 2001^145^ Operative approach BA | 1 | 58 | 0.02 (0.003–0.09)
Arthroscopic RCR | Lafosse 2007^122^ Operative approach BA | 2 | 17 | 0.12 (0.003–0.34)
Arthroscopic RCR | McBirnie 2005^130^ Operative approach BA | 1 | 53 | 0.02 (0.003–0.10)
Arthroscopic debridement & tenotomy | Klinger 2005^63^ Operative approach Retrospective cohort | 3 | 24 | 0.13 (0.04–0.31)
Arthroscopic debridement without tenotomy | Klinger 2005^63^ Operative approach Retrospective cohort | 0 | 17 | 0 (0.00–0.14)
Biceps tenotomy vs. tenodesis | Boileau 2007^75^ Operative approach Retrospective cohort | 1† | 72 | 0.01 (0.002–0.07)
Postoperative Rehabilitation
Continuous passive motion & PT program | LaStayo 1998^180^ Post-operative rehabilitation RCT | 0 | 17 | 0 (0.00–0.14)
PT alone | LaStayo 1998^180^ Post-operative rehabilitation RCT | 1 | 15 | 0.07 (0.01–0.30)

BA = before-and-after; CI = confidence interval; PT = physical therapy; RCR = rotator cuff repair; RCT = randomized controlled trial

† No group specification

Neurologic injury. Twelve studies (Table 42) (three trials,109,114,137 two cohort studies,112,113 and seven uncontrolled studies65,74,103,108,110,145,161) provided data on neurologic injury. Overall, the rates of injury from 10 studies that examined operative approach were consistent and ranged from 0 to 0.06. Two studies examining operative augmentation reported no events.

Table 42 Neurological injury

Intervention | Author, year Category Design | Events | Sample size | Rate (95% CI)
Operative
Open RCR | Gazielly 1994^103^ Operative approach BA | 2 | 100 | 0.02 (0.006–0.07)
Open RCR | Hsu 2007^108^ Operative approach BA | 0 | 47 | 0 (0.00–0.05)
Open RCR | Iannotti 2006^109^ Operative augmentation RCT | 0 | 15 | 0 (0.00–0.15)
Open RCR | Ide 2005^112^ Operative approach Prospective cohort | 3 | 50 | 0.06 (0.02–0.16)
Open RCR | Montgomery 1994^137^ Operative approach CCT | 1 | 50 | 0.02 (0.004–0.11)
Open RCR | Pai 2001^145^ Operative approach BA | 2 | 58 | 0.03 (0.01–0.12)
Mini-open RCR | Kim 2003^114^ Operative approach CCT | 0 | 34 | 0 (0.00–0.07)
Arthroscopic RCR | Boileau 2005^74^ Operative approach BA | 0 | 65 | 0 (0.00–0.04)
Arthroscopic RCR | Ide 2007^110^ Operative approach BA | 1 | 20 | 0.05 (0.01–0.24)
Arthroscopic RCR | Ide 2005^112^ Operative approach Prospective cohort | 0 | 50 | 0 (0.00–0.05)
Arthroscopic RCR | Kim 2003^114^ Operative approach CCT | 0 | 42 | 0 (0.00–0.06)
Arthroscopic RCR | Tauro 2004^161^ Operative approach BA | 0 | 42 | 0 (0.00–0.06)
Arthroscopic debridement | Klinger 2005^65^ Operative approach BA | 0 | 33 | 0 (0.00–0.08)
Arthroscopic debridement | Montgomery 1994^137^ Operative approach CCT | 0 | 38 | 0 (0.00–0.07)
Arthroscopic debridement with tenotomy | Klinger 2005^63^ Operative approach Retrospective cohort | 0 | 24 | 0 (0.00–0.10)
Arthroscopic debridement without tenotomy | Klinger 2005^63^ Operative approach Retrospective cohort | 0 | 17 | 0 (0.00–0.14)
Open RCR & porcine augmentation | Iannotti 2006^109^ Operative augmentation RCT | 0 | 15 | 0 (0.00–0.15)
McLaughlin procedure RCR | Ito 2003^113^ Operative technique Retrospective cohort | 0 | 17 | 0 (0.00–0.14)
Patch graft RCR | Ito 2003^113^ Operative technique Retrospective cohort | 0 | 13 | 0 (0.00–0.17)

BA = before-and-after; CCT = controlled clinical trial; CI = confidence interval; RCR = rotator cuff repair; RCT = randomized controlled trial

Reoperation—NOS. Nine studies provided data on the need for reoperation (three trials,114,136,137 four cohort studies,75,88,134,140 and two uncontrolled studies83,108) (Table 43). Overall, the rates of reoperation from eight studies that examined operative approach ranged from 0 to 0.24. Rates of reoperation for a variety of operative techniques were provided and ranged from 0.06 to 0.18.

Table 43 Reoperation—NOS

Intervention | Author, year Category Design | Events | Sample size | Rate (95% CI)
Operative
Open RCR | Cofield 2001^83^ Operative approach BA | 5 (hypertrophic bursal scar excision (2); glenohumeral arthritis (1); impaired healing due to renal failure (1); unknown (1) | 105 | 0.05 (0.02–0.11)
Open RCR | Hsu 2007^108^ Operative approach BA | 0 | 47 | 0 (0.00–0.05)
Open RCR | Mohtadi 2008^136^ Operative approach RCT | 0 | 29 | 0 (0.00–0.09)
Open RCR | Millar NL, 2009^134^ Operative approach/technique Retrospective cohort | 4^†^ | 20 | 0.2 (0.08–0.42)
Open RCR | Montgomery 1994^137^ Operative approach CCT | 4 | 50 | 0.08 (0.03–0.19)
Mini-open RCR | Kim 2003^114^ Operative approach CCT | 0 | 34 | 0 (0.00–0.07)
Mini-open RCR | Mohtadi 2008^136^ Operative approach RCT | 1^†^ | 31 | 0.03 (0.006–0.16)
Arthroscopic RCR | Kim 2003^114^ Operative approach CCT | 0 | 42 | 0 (0.00–0.06)
Arthroscopic RCR | Mullett 2006^140^ Operative approach Prospective cohort | 3 | 96 | 0.03 (0.01–0.09)
Arthroscopic subacromial decompression | Mullett 2006^140^ Operative approach Prospective cohort | 26 | 114 | 0.23 (0.16–0.31)
Arthroscopic debridement | Montgomery 1994^137^ Operative approach CCT | 9 | 38 | 0.24 (0.13–0.39)
Biceps tenotomy vs. tenodesis | Boileau 2007^75^ Operative approach Retrospective cohort | 2^*^ | 72 | 0.03 (0.008–0.10)
Mitek metal suture anchor (open RCR) | Cummins 2003^88^ Operative technique Prospective cohort | 1 | 18 | 0.06 (0.01–0.26)
Headed bio-corkscrews (open RCR) | Cummins 2003^88^ Operative technique Prospective cohort | 1 | 9 | 0.11 (0.02–0.43)
Arthroscopic knotted | Millar NL, 2009^134^ Operative approach/technique Retrospective cohort | 4^†^ | 29 | 0.14 (0.05–0.31)
Arthroscopic knotless | Millar NL, 2009^134^ Operative approach/technique Retrospective cohort | 7^†^ | 38 | 0.18 (0.09–0.33)

AC = acromioclavicular; BA = before-and-after; CCT = controlled clinical trial; CI = confidence interval; RCR = rotator cuff repair; RCT = randomized controlled trial

* No group specification

† Due to traumatic events

Postoperative sudden pain/impingement syndrome. One RCT182 provided data on postoperative sudden pain and impingement syndrome (Table 44). The rate of ostoperative sudden pain ranged from 0 in physical therapy alone to 0.03 in continuous passive motion with physical therapy program, while the rate of postoperative impingement syndrome ranged from 0 in continuous passive motion with physical therapy program to 0.05 in physical therapy alone.

Table 44 Postoperative pain or impingement syndrome

Intervention | Author, year Category Design | Posoperative pain/Impingement
Intervention | Author, year Category Design | Events | Sample size | Rate (95% CI)
Postoperative Rehabilitation
Continuous passive motion & PT program | Michael 2005^182^ Post-op rehabilitation RCT | 1/0 | 34 | 0.03 (0.005–0.15)/0 (0–0.07)
PT alone | Michael 2005^182^ Post-op rehabilitation RCT | 0/1 | 21 | 0 (0–0.11)/0.05 (0.009–0.23)

CI = confidence interval; PT = physical therapy; RCT = randomized controlled trial

Glenohumeral instability. One postoperative rehabilitation study180 provide data on glenohumeral instability in patients undergoing continuous passive motion or manual passive range of motion exercises (Table 45). Only one case of glenohumeral instability was reported in the manual passive range of motion exercise group.

Table 45 Glenohumeral instability

Intervention | Author, year Category Design | Events | Sample size | Rate (95% CI)
Postoperative Rehabilitation
Continuous passive motion | LaStayo 1998^180^ Post-op rehabilitation RCT | 0 | 17 | 0 (0.00–0.14)
Manual passive ROM exercises | LaStayo 1998^180^ Post-op rehabilitation RCT | 1 | 15 | 0.07 (0.01–0.30)

CI = confidence interval; RCT = randomized clinical trial; ROM = range of motion; post-op = postoperative

Fracture of the greater tuberosity. One prospective cohort study129 provide data on fracture of the greater tuberosity of humerus bone (Table 46). The rate of fracture of the greater tuberosity was 0.01 in the study.

Table 46 Fracture of the greater tuberosity

Intervention | Author, year Category Design | Events | Sample size | Rate (95% CI)
Operative
Mattress suture vs. transosseus suture (arthroscopic RCR) | Matis 2006^129^ Operative technique Prospective cohort | 1^*^ | 90 | 0.01 (0.002–0.06)

CI = confidence interval; RCR = rotator cuff repair

* No group specification

Biceps pathology. Two BA studies122,127 provided data on sublaxation or secondary rupture of the long head of biceps (LHB) tendon (Table 47). The rate of biceps complications in these studies investigating arthroscopic RCR and stabilization of LHB & open RCR was 0.12 and 0.14, respectively. One prospective cohort study64 provided data on biceps tendon disruption/inflammation (Table 19). The rate of biceps tendon disruption/inflammation in arthroscopic RCR with PGA tacs vs. suture tying was 0.16 (0.05 for disruption/0.10 for inflammation) with no group specification.

Table 47 Biceps pathology

Intervention | Author, year Category Design | Events | Sample size | Rate (95% CI)
Operative
Arthroscopic RCR | Lafosse 2007^122^ Operative approach BA | 2 | 17 | 0.12 (0.03–0.34)
Stabilization of LHB & open RCR | Maier 2007^127^ Operative approach BA | 3 | 21 | 0.14 (0.05–0.35)
Bioabsorbable PGA tacs vs. suture tying (arthroscopic RCR) | Bennett 2004^64^ Operative technique Prospective cohort | 3^*^ | 19 | 0.16 (0.06–0.38)

BA = before-and-after; CI = confidence interval; LHB = long head of biceps PGA = Polymerized lactic acid tack; RCR = rotator cuff repair

* No group specification

Deltoid disruption. Two studies (one trial109 and one BA study101) reported no deltoid disruption from operative interventions including open RCR, open debridement, and open RCR with augmentation (Table 48).

Table 48 Deltoid disruption

Intervention | Author, year Category Design | Events | Sample size | Rate (95% CI)
Operative
Open RCR | Iannotti 2006^109^ Operative augmentation RCT | 0 | 15 | 0 (0.00–0.15)
Open debridement & acromioplasy | Gartsman 1997^101^ Operative approach BA | 0 | 33 | 0 (0.00–0.08)
Open RCR & porcine augmentation | Iannotti 2006^109^ Augmentation RCT | 0 | 15 | 0 (0.00–0.15)

Heterotopic bone formation. One retrospective cohort study139 provide data on heterotopic bone formation (Table 49). The rate of heterotopic bone formation was 0.26 in the open or arthroscopic debridement group and 0.27 in the open RCR group.

Table 49 Heterotopic bone formation

Intervention | Author, year Category Design | Events | Sample size | Rate (95% CI)
Operative
Open RCR | Motycka 2004^139^ Operative approach Retrospective cohort | 9 | 33 | 0.27 (0.15–0.44)
Open or arthroscopic debridement | Motycka 2004^139^ Operative approach Retrospective cohort | 8 | 31 | 0.26 (0.14–0.43)

CI = confidence interval; RCR = rotator cuff repair

Arthropathy. One retrospective cohort study139 and one BA study156 provided data on arthropathy (Table 50). The cohort study compared open RCR with open or arthroscopic debridement and rates of postoperative AC joint arthrosis for the two arms were 1.0 and 0.42, respectively. The BA study examined arthroscopic debridement and reported a rate of 0.04.

Table 50 Arthropathy

Intervention | Author, year Category Design | Events | Sample size | Rate (95% CI)
Operative
Open RCR | Motycka 2004^139^ Operative approach Retrospective cohort | 29 | 29^†^ | 1 (0.91–1.0)
Open or arthroscopic debridement | Motycka 2004^139^ Operative approach Retrospective cohort | 10 | 24^†^ | 0.42 (0.24–0.61)
Arthroscopic debridement only | Scheibel 2004^156^ Operative approach BA | 1 | 23^*^ | 0.04 (0.008–0.21)

AC = acromioclavicular; BA = before-and-after; CI = confidence interval; RCR = rotator cuff repair

* Sample size represents the number of participants enrolled in the study because the patient with the event had reoperation and was excluded from the analysis.

† Sample size represents the number of patients without preoperative arthrosis on radiograph.

Hematoma. Four studies (three BA studies70,120,156 and one retrospective cohort study63) provided data on hematoma (Table 51). The rates from the three BA studies were consistent, 0.08, 0.06, and 0.05. The cohort study using arthroscopic debridement with and without tenotomy reported no events of hematoma in both groups.

Table 51 Hematoma

Intervention | Author, year Category Design | Events | Sample size | Rate (95% CI)
Operative
Arthroscopic RCR | Bennett 2003^70^ Operative approach BA | 2 | 24 | 0.08 (0.02–0.26)
Arthroscopic RCR | Kreuz 2005^120^ Operative approach BA | 1^*^ | 16 | 0.06 (0.01–0.28)
Arthroscopic debridement | Scheibel 2004^156^ Operative approach BA | 1 | 22 | 0.05 (0.008–0.22)
Arthroscopic debridement with tenotomy | Klinger 2005^63^ Operative approach Retrospective cohort | 0 | 24 | 0 (0.00–0.10)
Arthroscopic debridement without tenotomy | Klinger 2005^63^ Operative approach Retrospective cohort | 0 | 17 | 0 (0.00–0.14)

BA = before-and-after; CI = confidence interval; RCR = rotator cuff repair

* The patient developed post-operative stiffness (frozen shoulder) due to hematoma.

Seroma. One RCT,109 one retrospective cohort study170 and five uncontrolled studies76,83,92,93,101 provided data on seroma for operative approaches (Table 52). The rates of seroma were consistent for the uncontrolled studies, ranging from 0.01 to 0.06. However, two controlled studies examining the use of porcine augmentation with rotator cuff repair109,170 both found high rates of hypersensitive reaction in patients receiving the graft, with event rates of 0.2 and 0.3.

Table 52 Seroma

Intervention | Author, year Category Design | Events | Sample size | Rate (95% CI)
Operative
Open RCR | Cofield 2001^83^ Operative approach BA | 1 (at graft donor site) | 105 | 0.01 (0.002–0.05)
Open RCR | Iannotti 2006^109^ Operative augmentation RCT | 0 | 15 | 0 (0–0.15)
Open RCR | Walton 2007^170^ Operative augmentation Retrospective cohort | 0 | 15 | 0 (0–0.15)
Mini-open RCR | Boszotta 2004^76^ Operative approach BA | 1 (in the area of incision) | 84 | 0.01 (0.002–0.06)
Mini-open RCR | Deutsch 2008^92^ Operative approach Cohort – BA data | 1 | 39 | 0.03 (0.005–0.13)
Mini-open RCR | Ellman 1993^93^ Operative approach Cohort – BA data | 1 | 40 | 0.03 (0.004–0.13)
Open RCR & porcine augmentation | Iannotti 2006^109^ Augmentation RCT | 3 (reaction to graft) | 15 | 0.2 (0.07–0.45)
Open RCR & porcine augmentation | Walton 2007^170^ Operative augmentation Retrospective cohort | 4 (reaction to graft) | 15 | 0.3 (0.11–0.52)
Open debridement & acromioplasty | Gartsman 1997^101^ Operative approach BA | 2 | 33 | 0.06 (0.02–0.20)

BA = before-and-after; CI = confidence interval; RCR = rotator cuff repair; RCT = randomized controlled trial

Lymphedema. One BA study186 provided data on lymphedema (Table 53). The rate of lymphedema in the nonoperative treatment was 0.02.

Table 53 Lymphedema

Intervention | Author, year Category Design | Events | Sample size | Rate (95% CI)
Nonoperative
Nonoperative treatment (Analgesic, NSAID, steroid injection, reeducation program) | Ghroubi 2008^186^ Nonoperative BA | 1 | 59 | 0.02 (0.003–0.09)

BA = before-and-after; CI = confidence interval; NSAID = non-steroidal anti-inflammatory drug

Synovitis. Two BA studies67,130 provided data on synovitis (Table 54). There were no reactive synovitis events in patients undergoing arthroscopic RCR or open RCR with augmentation.

Table 54 Reactive synovitis

Intervention | Author, year Category Design | Events | Sample size | Rate (95% CI)
Operative
Arthroscopic RCR | McBirnie 2005^130^ Operative approach BA | 0 | 53 | 0 (0.00–0.05)
Open RCR & augmentation (polyester graft) | Audenaert 2006^67^ Operative augmentation BA | 0 | 39 | 0 (0–0.06)

BA = before-and-after; CI = confidence interval; RCR = rotator cuff repair

Local reaction to suture material. One retrospective cohort study157 provided data on local reaction to suture material (Table 55). The rate of local reaction to suture material ranged from 0 in the mini-open RCR to 0.03 in the arthroscopic RCR.

Table 55 Local reaction to suture material

Intervention | Author, year Category Design | Events | Sample size | Rate (95% CI)
Operative
Mini-open RCR | Severud 2003^157^ Operative approach Retrospective cohort | 0 | 29 | 0 (0.00–0.09)
Arthroscopic RCR | Severud 2003^157^ Operative approach Retrospective cohort | 1 | 35 | 0.03 (0.005–0.15)

CI = confidence interval; RCR = rotator cuff repair

Wound dehiscence. One CCT137 provided data on wound dehiscence (Table 56). The rate of dehiscence ranged from 0 for arthroscopic debridement and 0.02 for open RCR.

Table 56 Wound dehiscence

Intervention | Author, year Category Design | Events | Sample size | Rate (95% CI)
Operative
Open RCR | Montgomery 1994^137^ Operative approach CCT | 1 | 50 | 0.02 (0.004–0.11)
Arthroscopic debridement | Montgomery 1994^137^ Operative approach CCT | 0 | 38 | 0 (0.00–0.07)

CCT = controlled clinical trial; CI = confidence interval; RCR = rotator cuff repair

Delayed wound healing. One prospective cohort study147 provided data on wound healing (Table 57). The rate of delayed wound healing ranged from 0 in single-row arthroscopic RCR to 0.03 in double-row arthroscopic RCR.

Table 57 Delayed wound healing

Intervention | Author, year Category Design | Events | Sample size | Rate (95% CI)
Operative
Single-row fixation | Park 2008^147^ Operative technique Prospective cohort | 0 | 40 | 0 (0.00–0.06)
Double-row fixation | Park 2008^147^ Operative technique Prospective cohort | 1 | 38 | 0.03 (0.005–0.13)

CI = confidence interval

Cosmetic deformity. Three studies (one trial,114 one cohort study,63 and one uncontrolled study65) provided data on cosmetic deformity for operative approaches (Table 58). The rates from the three studies were consistent among designs and ranged from 0 to 0.08.

Table 58 Cosmetic deformity

Intervention | Author, year Category Design | Events | Sample size | Rate (95% CI)
Operative
Mini-open RCR | Kim 2003^114^ Operative approach CCT | 2 | 34 | 0.06 (0.02–0.19)
Arthroscopic RCR | Kim 2003^114^ Operative approach CCT | 0 | 42 | 0 (0.00–0.06)
Arthroscopic debridement only | Klinger 2005^65^ Operative approach BA | 1 | 33 | 0.03 (0.005–0.15)
Arthroscopic debridement with tenotomy | Klinger 2005^63^ Operative approach Retrospective cohort | 2 | 24 | 0.08 (0.02–0.26)
Arthroscopic debridement without tenotomy | Klinger 2005^63^ Operative approach Retrospective cohort | 0 | 17 | 0 (0.00–0.14)

BA = before-and-after; CCT = controlled clinical trial; CI = confidence interval; RCR = rotator cuff repair

Other medical complications. Eight studies reported on 12 other medical complications (Table 59): skin hypersensitivity,114 skin bulla,117 pneumonia,83 deep vein thrombosis,83,182 myocardial infarction,83 postoperative depression,83 laryngeal nerve palsy,146 facial nerve palsy,146 allergic reaction to oral anti-inflammatory drugs,130 massive intraoperative swelling of the neck,129 neck pain,117 and polymyalgia rheumatica.66 The rates for all events were consistent and ranged from 0 to 0.05 (Table 59).

Table 59 Other medical complications

Complication | Intervention | Author, year Category Design | Events | Sample size | Rate (95% CI)
Skin hypersensitivity | Mini-open vs. arthroscopic RCR | Kim 2003^114^ Operative approach CCT | 1^*^ | 76 | 0.01 (0.002–0.07)
Skin bulla | MCS repair | Ko S-H, 2009^117^ Operative technique CCT | 1 | 35 | 0.03 (0.005–0.15)
Skin bulla | Simple stitch repair | Ko S-H, 2009^117^ Operative technique CCT | 1 | 36 | 0.03 (0.005–0.14)
Pneumonia | Open RCR | Cofield 2001^83^ Operative approach BA | 1 | 105 | 0.01 (0.002–0.05)
DVT | Open RCR | Cofield 2001^83^ Operative approach BA | 1 | 105 | 0.01 (0.002–0.05)
DVT | Continuous passive motion & PT program | Michael 2005^182^ German Post-op rehab RCT | 0 | 34 | 0 (0.00–0.07)
DVT | PT alone | Michael 2005^182^ German Post-op rehab RCT | 1 | 21 | 0.05 (0.009–0.23)
MI | Open RCR | Cofield 2001^83^ Operative approach BA | 1 | 105 | 0.01 (0.002–0.05)
Postoperative depression | Open RCR | Cofield 2001^83^ Operative approach BA | 1 | 105 | 0.01 (0.002–0.05)
Laryngeal nerve palsy | Arthroscopic RCR | Park 2004^146^ Operative approach Cohort – BA data | 1 | 42 | 0.02 (0.004–0.12)
Facial nerve palsy | Arthroscopic RCR | Park 2004^146^ Operative approach Cohort – BA data | 1 | 42 | 0.02 (0.004–0.12)
Allergic reaction to oral anti-inflammatory drugs | Arthroscopic RCR | McBirnie 2005^130^ Operative approach BA | 1 | 53 | 0.02 (0.003–0.10)
Massive intraoperative swelling of the neck | Mattress suture vs. transosseus suture (arthroscopic RCR) | Matis 2006^129^ Operative technique Prospective cohort | 1^*^ | 90 | 0.01 (0.002–0.06)
Neck pain | MCS repair | Ko S-H 2009^117^ Operative technique CCT | 1 | 35 | 0.03 (0.005–0.15)
Neck pain | Simple stitch repair | Ko S-H 2009^117^ Operative technique CCT | 1 | 36 | 0.03 (0.005–0.14)
Polymyalgia rheumatica | Open OR Mini-open RCR (+acromioplasty) | Moosmayer 2010^66^ Non-operative vs. operative | 0 | 52 | 0 (0.00–0.05)
Polymyalgia rheumatica | Nonoperative (PT) | Moosmayer 2010^66^ Non-operative vs. operative | 1 | 51 | 0.02 (0.003–0.10)

BA = before-and-after; CCT = controlled clinical trial; CI = confidence interval; DVT = deep vein thrombosis; MI = myocardial infarction; PT = physical therapy; RCR = rotator cuff repair; RCT = randomized controlled trial

* No group specification

### Question 6. Evidence on the Role of Prognostic Factors on Treatment Outcomes

Summary. Overall, 72 of the 137 studies examined the impact of prognostic factors on patient outcomes. General conclusions are limited due to the varied methodologies across studies, particularly the different outcomes for which prognostic factors were evaluated. Variations in findings may also be due to limited sample sizes and potential for type II errors, i.e., failing to find a difference when one actually exists.

Among operative studies, 65 of 113 studies examined prognostic factors. The factors most often examined were:

- Tear size (n=39): Twenty-two studies found evidence of worse outcomes for larger tears, while 16 studies found no impact of tear size. One study made no conclusions.71 Most of the studies evaluated operative approaches and there were no patterns in terms of findings by specific operative approach.
- Age (n=28): Fifteen studies found evidence of worse outcomes among older patients, while 13 studies found no impact of age. Most of the studies evaluated operative approaches, and no patterns were seen by operative approach.
- Sex (n=16): Ten studies found no differences in outcomes for men and women. Six studies found differences, however the findings differed with three studies showing better outcomes for women (open RCR,128 arthroscopic RCR,100 nonabsorbable vs. absorbable sutures73) and three studies favouring men (open RCR,83 arthroscopic RCR,80 arthroscopic single row vs. double row105).
- WCB status (n=12): Ten studies found no impact of WCB status for open RCR (n=3), arthroscopic RCR (n=6), and nonabsorbable vs. absorbable sutures (n=1). Two studies (open RCR vs. mini-open vs. arthroscopic RCR,107 arthroscopic RCR80) showed worse outcomes for patients with WCB claims.
- Duration of symptoms (n=13): Thirteen studies showed no evidence for different outcomes based on duration of symptoms. These included evaluations of arthroscopic RCR (n=6), mini-open or arthroscopic (n=1), open (n=4), arthroscopic debridement (n=1), and open vs. arthroscopic (n=1).
- Preoperative stiffness, range of motion, or strength (n=10): Five uncontrolled studies examining arthroscopic (n=2) and open (n=3) repairs and one controlled study examining arthroscopic repairs (n=1) showed worse outcomes with greater preoperative symptoms. In one study,134 outcomes were similar for open and arthroscopic groups, depending on the preoperative symptoms investigated. The remaining three studies114,141,144 showed no difference in outcomes based on preoperative symptoms.

Among the other interventions examined in this report, four of eleven studies that evaluated postoperative rehabilitation, two of 10 studies evaluating nonoperative interventions, and one of five studies comparing operative with nonoperative interventions examined the impact of various prognostic factors. The variation in interventions, factors that were examined, and findings across studies preclude any overall interpretations or conclusions.

Prognostic factors by intervention and outcome. We aimed to identify the role of prognostic factors (e.g., patient and clinical characteristics) as moderators of the treatment effect measured in nonoperative, operative and postoperative rehabilitation studies assessing RC tears. Overall, the impact of prognostic factors on patient outcomes was assessed through either subgroup, regression or non-parametric analysis in 72 studies. Due to the small number of studies addressing each intervention and comparison, meta-regression analysis was not feasible. Therefore, the findings from the individual studies that reported data on the role of prognostic factors are presented.

#### Operative Studies

Of the 113 studies examining the effectiveness of operative interventions, 65 studies (five RCTs,71,73,105,109,133 one CCT,114 seven prospective cohort studies, 64,72,77,112,117,147,148 eight retrospective cohort studies,68,75,119,125,134,154,157,173 12 cohort studies with BA data,62,86,92,93,107,128,135,141,144,149,162,164 and 32 BA studies60,65,70,74,76,80,83,84,89,90,99–101,103,104,108,110,115,116,120–124,130,131,142,145,151,160,166,174) explored the role of various patient or clinical factors as prognostic factors. Six of the studies focused on operative techniques,64,71,73,105,117,147 three focused on augmentations,99,109,174 and 55 studies examined operative approaches. One study investigated both operative approaches and techniques.134 The prognostic factors were examined using subgroup analysis in 45 studies, regression analysis in 15 studies, both subgroup and regression in two studies, non-parametric tests in two studies, and both subgroup analysis and non-parametric tests in one study. The analysis was planned a priori in 39 studies, while 26 studies conducted the analysis post hoc.

Five studies72,100,107,144,160 conducted an analysis of the role of prognostic factors on health-related quality of life. The studies used multiple regression models160 or subgroup analysis72,100,107,144 to examine a variety of prognostic factors, including age,100 sex,100 tear size,72,100 WCB status,107 number of comorbidities,160 and preoperative stiffness.144 A variety of potential confounding factors were controlled in two studies144,160 but they were not explored in the analysis. The investigators of one study concluded that age, but not sex, influences health-related quality of life outcomes. They found that older patients had less improvement in the SF-36 after arthroscopic repair.100 In studies investigating tear size, no significant differences in health related quality of life outcomes for patients with small and large tears were found.72,100 The author conclusions for other prognostic factors are presented in Table 62.

Table 62 Prognostic factors in operative studies

Author, year Study design | Intervention Followup, mean (range) | Type of analysis | Outcome variable | Authors’ conclusions
Baker CL,68 1995 Retrospective cohort | G1: Open RCR G2: Mini-open RCR 3.3 yr | Subgroup analysis by tear size (post hoc) | UCLA cuff integrity | All small tears had good-to-excellent results. With large tears, more patients had good-to-excellent results in open than mini-open repair group. Cuff was more likely to be intact for smaller size tear.
Bennett WF,62 2003 BA | Open RCR 3.2 yr (2–4) | Subgroup analysis by tear orientation (a priori) | ASES CMS % function pain | There is no statistical difference between anterosuperior and posterosuperior tear types for any of the outcomes.
Bennett WF,70 2003 BA | Arthroscopic RCR NR (2–4 yr) | Subgroup analysis by age and sex (post hoc) | ASES CMS pain | Age or sex were not associated with outcomes.
Bennett WF,64 2003 Prospective cohort | G1: Bioabsorbable tacs G2: Suture tying NR (2–4 yr) | Subgroup analysis by sex (a priori) | ASES CMS pain | No significant impact of sex on outcomes.
Bigoni M,71 2009 RCT | G1: Side-to-side repair (25) G2: Tendon-to- bone fixation (25) 12 mo | Subgroup analysis by tear size (a priori) | CMS strength | No conclusions were made due to a small number of patients.
Bishop J,72 2006 Prospective cohort | G1: Open / mini- open RCR G2: Arthroscopic RCR 12 mo | Subgroup analysis by tear size (post hoc) | SF-36 ASES CMS ROM pain cuff integrity | In the open repair group, smaller tear size tended to have better, but non-significant, functional outcome scores including pain score, F and ER strength testing. In the arthroscopic group, smaller tears have significantly better outcomes except in pain which showed non-significant improvement. Tear size was associated with cuff integrity in the arthroscopic group but not in the open group.
Boehm TD,73 2005 RCT | G1: Nonabsorbable sutures (Mason- Allen technique) G2: Absorbable sutures (Kessler technique) 2.2 yr (2–2.5) | Regression analysis controlling for hand dominance, WCB status, age, sex, tear size, and type of suture (a priori) | CMS | No significant influence of hand dominance, WCB status, tear size, and suture type on outcome. Male gender and older patients had significantly worse outcomes.
Boileau P,75 2007 Retrospective cohort | G1: Biceps tenotomy G2: Biceps tenodesis 2.9±0.6 yr (2–6.3) | Regression analysis controlling for number of tendons torn, extension of tear, fatty infiltration, acromiohumeral distance, and atrophy of teres minor (post hoc) | CMS ROM | No significant effect of number of tendons torn or the extension of tear on functional outcomes. Fatty infiltration and acromiohumeral distance did not have a measurable effect on the outcome. Pre-op absence or atrophy of teres minor was associated with fatty infiltration of infraspinatus and significantly worse outcomes compared to patients with healthy teres minor.
Boileau P,74 2005 BA | Arthroscopic RCR 2.4 yr (2–3.8) | Multiple regression analysis controlling for age, sex, (a priori) tear size, duration of symptoms, WCB status, additional procedures (post hoc) | cuff integrity | Tendon healing was negatively associated with increasing age and delamination of the subscapularis or infraspinatus tendon. Small tear size was positively associated with tendon healing. No association between tendon healing and sex, duration of symptoms, previous injections, WCB status, or additional procedures.
Boszotta H,76 2004 BA | Mini-open RCR 2.9 yr (2.3–3.7) | Subgroup analysis by age, tear size, tear pattern, closure technique, number of sutures, quality and condition of long biceps tendon, acromion type, acromiohumeral distance, and immobilization (post hoc) | CMS UCLA | Larger tear size was associated with worse outcome. The quality and condition of long biceps tendon was associated with outcome. Patients with curved or hooked acromion types have significantly better outcomes than patients with flat-shaped acromion. There was no significant influence of age, pre-op acromiohumeral distance, tear configuration, closure technique, number of sutures or type and duration of immobilization on outcome.
Buess E,77 2005 Prospective cohort | G1: Open or mini- open RCR G2: Arthroscopic RCR 2 yr (15 mo–3.3 yr) | Subgroup analysis by tear size (a priori) | SST | No significant effect of tear size on outcome for both groups.
Charousset C,80 2008 BA | Arthroscopic RCR 2 yr (maximum) | Multiple regression analysis controlling for age, sex, dominant side affected, upper-limb heavy work, WCB status, duration of symptoms, mechanism of tearing, number of tendons torn, extension and retraction of lesion, tendon quality, bone quality, and tendon reducibility (a priori) | CMS | Women had significantly worse outcome than men. Upper-limb heavy work was negatively associated with outcome. Poor bone quality was found to be associated with poor functional recovery. No significant effect of age, dominant side, duration of symptoms, mechanism of tearing, type of job, involvement of multiple tendons, fatty degeneration, supraspinatus tear extent in sagittal or coronal planes, or AC joint involvement on functional outcome. Sex, age, tears involving 3 tendons and pre-op strength were predictive of post-op strength recovery in CMS subscale. No effect of WCB on functional outcome but time to recovery was longer.
Cofield RH,83 2001 BA | Open RCR 13.4 yr (2–22) | Subgroup analysis by age, sex, tear size, etiology of tear, side affected, hand dominance, duration of symptoms, shape of acromion, location of the tear, biceps tenodesis, and type of immobilization (post hoc) | pain active ROM strength | Patients with large or massive tears had lower active ROM and strength measures than patients with smaller tears. There was a trend for more pain with a larger tear size but this association was not significant. Men had significantly better active abduction and less pain than women. Older age was associated with lower active ROM and strength. Pre-op ROM and strength was associated with post-op ROM and strength. Etiology of tear, side of the repair, hand dominance, symptom duration, shape of acromion, location of the tear, biceps tenodesis, and type of immobilization did not influence outcome.
Cole BJ,84 2007 BA | Arthroscopic RCR 2.7 yr (2–3.8) | Subgroup analysis by age, sex, hand dominance, time to surgery, WCB status, biceps procedure, number of suture anchors and tear pattern (post hoc) | CMS Rowe score SST pain cuff integrity | Older patients had significantly more pain and less ER power. WCB status did not affect pain assessment, functional outcome scores, or ROM. Older age and pre-op extension of the tear into the infraspinatus were associated with recurrent tears. Concomitant biceps procedures, number of suture anchors used, time to surgery, gender, dominant or non dominant side, WCB status, and tear pattern were not associated with recurrent tears.
Cools A,86 2006 Prospective cohort as BA | Open RCR 18 mo (12–20) | Subgroup analysis by pre- op strength (post hoc) | CMS | Pre-op strength was positively correlated with functional outcome.
Davidson PA,89 2000 BA | Open or arthroscopic RCR 2 yr (minimum) | Regression analysis controlling for repair tension (a priori) | CMS pain | Increased tension on RCR was significantly associated with worse outcomes.
DeFranco MJ,90 2007 BA | Arthroscopic RCR 22.3 mo–(12 mo 3 yr) | Multiple regression analysis controlling for age (a priori) | cuff integrity | Younger patients had significantly better outcomes than older patients.
Deutsch A,92 2008 Prospective cohort as BA | Arthroscopic RCR 3.2 yr (2–5) | Subgroup analysis by number of tendons torn, tear size, tear pattern, presence of biceps tearing, and duration of pre-op symptoms (a priori) | ASES ROM strength pain cuff integrity | No significant effect of number of tendons torn or tear size on outcomes. Tear recurrence was significantly correlated with asymmetric retraction. No significant influence of biceps tears or duration of pre-op symptoms on tear recurrence.
Ellman H,93 1993 Prospective cohort as BA | Arthroscopic RCR 3.6 yr (2–7.3) | Subgroup analysis by tear size (a priori) | UCLA | Small tears associated with higher UCLA score than large tears.
Fuchs B,99 2006 BA | Open RCR & augmentation 3.2 yr (2–4.4) | Subgroup analysis by tear orientation, muscle atrophy (a priori). | CMS cuff integrity | There was no significant difference in the total CMS score between patient with supraspinatus tears and those with subscapularis tears. However, patients with subscapularis tears experienced significantly more pain at followup, as measured by the CMS pain subscale. Muscle atrophy approached significance as a predictor for retear.
Gartsman GM,100 1998 BA | Arthroscopic RCR 12.7 mo (11–21) | Subgroup analysis by age, sex, and tear size (a priori) | SF-36 ASES CMS | Older patients had significantly less improvement in SF-36. Female patients had significantly greater improvements in CMS and ASES than male patients. Tear with a greater length, width, and area had significantly less improvement in the strength score in CMS.
Gartsman GM,101 1997 BA | Open debridement & acromioplasty 5.3 yr (4–9.8) | Subgroup analysis by type and condition of tear (post hoc) | CMS UCLA SSI | All patients with severe superior migration of the humeral head had poor ROM, function, and strength. Poor outcomes were associated with irreparable tears of the subscapularis or teres minor, muscular atrophy of these two muscles, and moderate-to-severe superior migration of the humeral head.
Gazielly DF,103 1994 BA | Open RCR 4 yr (2–6) | Subgroup analysis by tear size, degree of occupational use, age (a priori) | cuff integrity | Age, size of tear, and occupational use was associated with tear recurrence.
Gladstone JN,104 2007 BA | Open or mini-open or arthroscopic RCR 12 mo (12–15) | Regression analysis controlling for fatty infiltration and muscle atrophy of supraspinatus and infraspinatus, and tear size (a priori) | ASES CMS strength cuff integrity | Patients with poor muscle quality had significantly less improvement in outcomes. Muscle atrophy and fatty infiltration have a strong negative effect on functional outcomes and strength. Pre-op tear size was the only significant predictor of cuff integrity, but it did not predict functional outcome or strength.
Grasso A,105 2009 RCT | G1: Arthroscopic single row repair (37) G2: Arthroscopic double row repair (35) 24.8±1.4 mo | Multiple regression analysis controlling for age, sex, dominance, location, shape, area of cuff tear, tendon retraction, fatty degeneration, treatment of the biceps tendon, preoperative strength (a priori) | DASH CMS Work-DASH strength | Age had a significant negative correlation with CMS. Sex was significantly correlated with DASH and strength. Preoperative strength was associated with postoperative strength. All other variables had no significant correlations with outcome in multivariate analysis.
Henn RF,107 2008 Prospective cohort as BA | Open or mini-open or arthroscopic RCR 12.3 ± 1.7 mo (7.4–20.2) | Subgroup analysis by WCB status. Multiple regression analysis controlling for multiple confounders (age, sex, smoking, expectations, number of comorbidities, education, marital status, work demands, and tear size) (a priori) | SF-36 DASH | Patients with WCB claims reported worse outcomes, after controlling for confounding factors. WCB patients were significantly younger, had greater work demands, and had lower marital rates, education levels, and pre-op expectations for the outcome.
Hsu SL,108 2007 BA | Open RCR 4.1 yr (2–7.1) | Subgroup analysis by presence of diabetes, and tear type (a priori). Non-parametric analysis for age (post hoc). | CMS | No statistical difference between patients with and without DM in total CMS. Patients with partial tears had significantly better total CMS scores than those with complete or large tears. Age was associated with strength score.
Iannotti JP,109 2006 RCT | G1: Porcine submucosa augmentation G2: No augment 14 mo (12 mo–2.2 yr) | Regression analysis controlling for tear size (a priori) | cuff integrity | Large tears were significantly more likely to heal than massive tear in both groups.
Iannotti JP,60 1996 BA | Open RCR NR | Subgroup analysis by WCB status, tear size, biceps tendon rupture, quality of remaining cuff tissue, and difficulty of repair (a priori) | CMS | WCB status and premorbid activity level did not influence functional outcome. Patients with larger tear sizes had significantly worse outcomes than patients with smaller tear sizes. Biceps tendon rupture, poor tissue quality, and difficulty of tendon mobilization were adversely associated with functional outcome.
Ide J,110 2007 BA | Arthroscopic RCR 3 yr (2–5) | Subgroup analysis by age, degree of tendon retraction, tear pattern and size (post hoc) | cuff integrity | Patients with severe tendon retraction had significantly more recurrences than those with minimal or moderate retraction. Significantly more failed repairs in older age than younger age. No significant effect of tear pattern and size on tear recurrence.
Ide J,112 2005 Prospective cohort | G1: Open RCR G2: Arthroscopic RCR 4.1 yr (2.1–6.9) | Subgroup analysis by tear size (post hoc) | UCLA JOA | Small tears had significantly better outcomes compared with large tears regardless of operative group.
Kim SH,114 2003 CCT | G1: Mini-open RCR G2: Arthroscopic RCR 3.3 yr (2.0–5.3) | Subgroup analysis by tear size, etiology of tear, acromial morphology, symptoms duration, and pre-op strength (a priori) | UCLA ASES pain | Larger tears had significantly worse scores on the UCLA, ASES, and function-VAS, but not pain-VAS. No other pre-op factors had a significant correlation with outcomes.
Kirschenbaum D,115 1993 BA | Open RCR 12 mo (maximum) | Non-parametric analysis of tear size (post hoc) | strength | Tear size was not significantly associated with strength; however, abduction and flexion strength was consistently less in patients with large or massive tears.
Klepps S,116 2004 BA | Open or mini-open RCR 12 mo (minimum) | Subgroup analysis by tear size (post hoc) | ASES CMS UCLA pain cuff integrity | Larger or massive tear size was associated with worse, but non-significant, functional outcomes (CMS, UCLA, ASES) and pain score, and were more likely to retear than small or medium tears.
Klinger HM,65 2005 BA | Arthroscopic debridement only 2.6 yr (2–3.8) | Subgroup by tear type, presence of subscapularis tear, superior migration of humeral head, decreased ROM, glenohumeral arthritis (post hoc) | CMS | The presence of two or more of these prognostic factors is correlated with poor outcome.
Ko S-H,117 2009 Prospective cohort | G1: Massive cuff stitch repair (35) G2: Simple stitch repair (36) 2.8 (2–3.4) yr | Non-parametric analysis by tear size and configuration (post hoc) | cuff integrity | No effect of tear size and configuration on cuff integrity.
Kose KC,119 2008 Retrospective cohort | G1: Mini-open RCR G2: Arthroscopic RCR 2.2 yr (12 mo–6.8 yr) | Subgroup analysis by age (post hoc) | CMS UCLA | There was a significant negative association between age and pain in the mini-open group. Age was not associated with the CMS score.
Kreuz PC,120 2005 BA | Arthroscopic RCR 3 yr (2–4) | Subgroup analysis by tear type (a priori) | CMS | Complete tears had significant improvement in outcomes compared to partial tears. Delay between trauma and outcome was inversely proportional.
Lafosse L,121 2007 BA | Arthroscopic RCR 3 yr (2–4.8) | Regression analysis controlling for etiology of tear, age, duration of symptoms, WCB status (a priori) and tear size (post hoc). | CMS pain active ROM strength | Etiology of tear, age, duration of symptoms, concomitant biceps procedures, pre-op status of the biceps tendon, degree of fatty infiltration, and WCB status did not affect outcomes. Large/massive tears were associated with more post-op weakness than small tears but no significant difference were found for pain, CMS score, or active ER or IR.
Lafosse L,122 2007 BA | Arthroscopic RCR 2.4 yr (2–3.3) | Multiple regression analysis controlling for age, mechanism of injury, duration of symptoms, and degree of fatty infiltration (a priori); WBC status, tear size and biceps pathology (post hoc) | CMS UCLA | No significant effect of age, duration of symptoms, WCB status, tear etiology, tear size, and biceps pathology on outcomes. The effect of rerupture and persistent fatty degeneration could not be determined.
Levy,123 2008 BA | Arthroscopic RCR 3.2 yr (2–6.1) | Subgroup analysis by tear size (a priori) | CMS | Small tears had significantly better outcomes than large tears.
Lichtenberg S,124 2006 BA | Arthroscopic RCR 2.2 yr | Subgroup analysis by age, tear size, grade of retraction, and biceps pathology (post hoc) | CMS cuff integrity | No significant effect of tear size, retraction, or biceps pathology on outcome measures. Age was a negative prognostic factor for retears.
Liem D,125 2007 Retrospective cohort | G1: Mini-open RCR G2: Arthroscopic RCR 12 mo (minimum) | Subgroup analysis by age and tear size (post hoc) | CMS ROM cuff integrity | No significant effect of tear size on outcomes. Age was a negative prognostic factor for retears.
Mallon WJ,128 2004 Retrospective cohort as BA | Open RCR 12 mo (minimum) | Subgroup analysis by smoking status and sex (a priori). Multiple regression analysis controlling for age, smoking status, tear size, and WBC status (a priori). | UCLA pain | Non-smokers had significantly greater improvement in UCLA and post-op pain scores than smokers. Women had greater improvement in the UCLA score between pre-op and post-op assessment, compared with men. Age, tear size and WCB status were not found to predict outcomes.
McBirnie JM,130 2005 BA | Arthroscopic RCR 2.4 yr (2–5) | Subgroup analysis by age, sex, WCB status (a priori), and tear size (post hoc) | CMS | No significant effects of WCB status, tear size, and additional procedures on outcome. No analysis of age and sex as planned.
McCallister WV,131 2005 BA | Open RCR 5.5±2.2 yr (2–10) | Subgroup analysis by age, sex, and number of tendons torn (post hoc) | SST | No significant effect of age and sex. Participants with a lower number of tendons torn had significantly better outcomes than patients with a higher number.
Milano G,133 2007 RCT | G1: Arthroscopic RCR & acromioplasty G2: Arthroscopic RCR 2 yr | Multiple regression analysis controlling for age, sex, dominance, location, shape, area, retraction, reducibility of cuff tear, fatty degeneration, involvement of subscapularis tendon, LHB treatment and type of acromion (a priori) | CMS DASH | Age was significantly positively associated with DASH scores. Gender and dominance did not significantly influence outcomes. There was no significant effect of location and area of tears on outcome. Tears that were U-shaped, retracted, partially reducible, involved the subcapularis, or had severe fatty degeneration had significantly worse outcomes.
Millar NL,134 2009 Retrospective cohort | G1: Open repair (20) G2: Arthroscopic knotted (29) G3: Arthroscopic knotless (38) 2 yr | Multiple regression analysis controlling for age, tear size, duration of symptoms, preoperative F and SS strength, preoperative stiffness, operative time, and surgical learning curve (a priori) | ASES cuff integrity | Preoperative SS strength was significantly associated with ASES score. There was no significant effect of stiffness, operative time, preoperative tear size, surgical learning curve on ASES score. Shorter operative time and smaller tear size was associated with lower retear rate. No significant association was found between age, duration of symptoms, preoperative F, SS strength, surgical learning curve, and the rate of cuff integrity.
Misamore GM,135 1995 Retrospective cohort as BA | Open RCR 3.8 yr (2–5.7) | Subgroup analysis by WCB status (a priori) | UCLA return to work | Patients without a WCB claim had significantly better outcomes as measured by the UCLA total score and individual subscores compared to those with a WCB claim. A significantly higher proportion of patients not receiving WCB returned to work compared to WCB patients.
Nam SC,141 2008 Prospective cohort as BA | Arthroscopic RCR 2.6 yr (16 mo–6.2 yr) | Subgroup analysis by pre-op shoulder stiffness (a priori) | CMS SST UCLA pain ROM strength | Pre-op shoulder stiffness was not associated with outcomes.
Nho SJ,142 2009 BA | Arthroscopic RCR 2.4 yr | Multiple regression analysis controlling for age, tear size and number of torn tendons (a priori) | ASES cuff integrity | Increased age, tear size and number of torn tendons were found to be significant predictors of tendon defect after repair. Patients without biceps or AC joint pathology and with normal tissue quality were significantly less likely to have a post-op tendon defect. Concomitant AC joint coplaning or distal clavicle excision was significantly negatively associated with ASES score.
Oh JH,144 2008 Prospective cohort as BA | Open or arthroscopic RCR 15.1 mo (12 mo–2.7 yr) | Subgroup analysis by pre-op stiffness (a priori) | SF-36 ASES CMS SST | No significant effect of shoulder stiffness on outcomes.
Pai VS,145 2001 BA | Open RCR 2.8 yr | Subgroup analysis by age, duration of symptoms, pre-op range of motion and strength, tear size, and quality of tendon (a priori) | CMS UCLA | No significant effect of age and duration of symptoms on outcome. Patients with poor pre-op ROM and strength or poor tendon quality had worse outcomes. Patients with massive tears had significantly worse outcomes than patients with other tear sizes but there was no overall significant effect of tear size on outcome.
Park JY,147 2008 Prospective cohort | G1: Double-row anchor RCR G2: Single-row anchor RCR 2.1 yr (22 mo–2.5 yr) | Subgroup analysis by tear size (post hoc) | ASES CMS SSI | Large to massive tears had significantly poorer outcomes than small tears when treated with single-row repair fixation.
Pearsall AW,148 2007 Prospective cohort | G1: Mini-open RCR (25) G2: Arthroscopic RCR (27) 4.2 yr (2.3–7) | Subgroup analysis by age, sex, tear size, smoking, osteoarthritis, diabetes, biceps pathology, concomitant distal clavicle excision (a priori) | SST^*^ UCLA pain (VAS)^*^ ROM^*^ | There was an inverse correlation between smoking and improvement in SST. Patients with larger tears had significantly less improvement in pain than patients with smaller tears. Presence of glenoid or humeral osteoarthritis had a significant effect on UCLA score. There was no significant effect of age, sex, presence of diabetes, biceps pathology, or concomitant distal clavicle excision on outcome improvements.
Pillay R,149 1994 Retrospective cohort as BA | Arthroscopic RCR 18.6 mo (6 mo–2.5 yr) | Subgroup analysis by tear type (a priori) | UCLA | There was no association between tear type and UCLA functional score.
Prasad N,151 2005 BA | Open RCR 2.2 yr (12 mo–4.2) | Subgroup analysis by age, sex, tear size, BMI, smoking status, and duration of symptoms (post hoc) | CMS pain | Older patients and patients with massive tears showed significantly less improvement in outcome compared to younger patients and patients with smaller tears. BMI, gender, smoking, and duration of symptoms did not affect the outcome.
Sauerbrey M,154 2005 Retrospective cohort | G1: Mini-open RCR G2: Arthroscopic RCR 2.1 yr (13 mo–4 yr) | Subgroup analysis by tear size (a priori) | Modified emsp;ASES | Surgical approaches were effective regardless of tear size.
Severud EL,157 2003 Retrospective cohort | G1: Mini-open RCR G2: Arthroscopic RCR 3.7 yr (2–6.8) | Subgroup analysis by tear size (post hoc) | ASES UCLA | No significant effect of tear size on outcomes.
Tashjian RZ,160 2006 BA | Open or mini-open or arthroscopic RCR 12 mo (maximum) | Multivariate regression analysis for number of comorbidities, with age, sex, WCB status, number of prior non-shoulder surgeries, smoking, tear size, symptom duration, and expectation as confounding variables (a priori). | SF-36 DASH SST VAS (pain, function, QOL) | Greater number of comorbidities was associated with significantly worse final scores on four SF- 36 subsections (bodily pain, general health, role emotional, and vitality). Patients with more comorbidities showed significantly greater improvement on the VAS, DASH and SST than patients with fewer comorbidities.
Tauro JC,162 2006 Retrospective cohort as BA | Arthroscopic RCR 2 yr | Subgroup analysis by tear size, pre-op stiffness (a priori) | Total passive ROM deficit (TROMD) | Tear size represented as a cuff tear index (CTI) was positively correlated with TROMD, where larger tear size was associated with more stiffness. Patients with pre-op stiffness were more likely to experience post-op stiffness.
Trenerry K,164 2005 Case-control as BA | Open RCR 17.3 mo (15.5–19) | Subgroup analysis by age, sex, hand dominance, affected side, symptom duration, mechanism of onset, WCB status, tear size, tear type, shoulder comorbidities, pre-op ROM (a priori) | ROM | There were no significant effects of any factors, with the exception of pre-op ROM restriction of hand behind the back, which was a significant predictor of post-op shoulder stiffness.
Vaz S,166 2000 BA | Arthroscopic debridement only 3.1 yr (12 mo–4 yr) | Subgroup analysis by age, sex, side of tear, nature of job, pre-op latency, acromion morphology and condition of cuff (post hoc) | CMS | There was no significant impact of any of the factors on outcome, except that patients with sedentary jobs returned to work significantly sooner than manual laborers.
Youm T,173 2005 Retrospective cohort | G1: Mini-open RCR G2: Arthroscopic RCR 3.0 yr (2.0–5.8) | Subgroup analysis by tear size (post hoc) | ASES UCLA | No significant effect of tear size within or between operative groups.
Zumstein MA,174 2008 BA | Open RCR & augmentation 9.9 yr (6.7–12.8) | Subgroup analysis by number of tendons torn and tear orientation (post hoc) | CMS | Number of tendons torn and tear type had no impact on post-op functional scores. However, patients with anterosuperior tears and those with three-tendon tears showed significantly greater gain compared to their pre-op state than did the two-tendon tears and posterosuperior tears.

AC joint = acromioclavicular joint; ASES = American Shoulder and Elbow Scale; BA = before-and-after; BMI = body mass index; CCT = controlled clinical trial; CMS = Constant-Murley score; DASH = Disabilities of the Arm, Shoulder and Hand; DM = diabetes mellitus; ER = external rotation; F = flexion; G = group; JOA = Japanese orthopaedic association; LHB = long head of biceps; mo = month; NR = not reported; PENN = University of Pennsylvania Shoulder Score; pre-op = preoperative; QOL = quality of life; RCR = rotator cuff repair; RCT = randomized controlled trial; ROM = range of motion; SF-12 = Short form-12; SF-36 = Short Form-36; SS = supraspinatus; SSI = shoulder strength index; SST = simple shoulder test; UCLA = University of California Los Angeles Scale; VAS = visual analogue scale; WCB = workers’ compensation board; yr = year

* Scores are improvement measures

Fifty-five studies60,62,64,65,68,70–73,75–77,80,84,86,89,92,93,99–101,104,105,107,108,112,114,116,119–125,128,130,131,133–135,141,142,144,145,147–149,151,154,157,160,166,173,174 conducted an analysis of the role of prognostic factors on functional outcome measures. The studies used subgroup analysis,60,62,64,65,68,70–72,76,77,84,92,93,99–101,107,108,112,114,116,119,120,123–125,130,131,135,141,144,145,147–149,151,154,157,166,173,174 multiple regression analysis73,75,80,90,104,105,109,121,122,128,133,134,142,160 to examine a various prognostic factors, including age,70,73,76,80,84,100,105,108,119,121,122,124,125,128,130,131,133,134,142,145,148,151,166 sex,64,70,80,100,105,128,130,131,133,148,151,166 tear size,60,68,71,72,76,77,92,93,100,104,105,112,114,116,121–125,128,130,134,142,145,147,148,151,154,157,173 duration of symptoms, 80,92,114,121,122,134,145,151 etiology of tear,114,121,133 tear pattern,76,92,105 tear type,62,65,75,99,108,120,149,174 location,105 number of tendons torn,75,92,131,142,174 hand dominance,73,80,105,133,166 preoperative strength,86,105,114,134,145 preoperative shoulder stiffness,134,141,144 preoperative range of motion,65,145 preoperative latency,166 mechanism of injury,122 smoking status,128,148,151 body mass index,151 number of comorbidities,160 WCB status,60,73,80,84,107,121,122,130,135 upper-limb heavy work,80 nature of work,166 repair tension,89 fatty infiltration,75,104,105,122,133 muscle atrophy,104 quality and condition of the biceps tendon,60,76,92,105,122,124,133,148 tissue quality,60,145,166 operative time,134 surgical learning curve,134 difficulty of repair,60 tendon retraction,105,124 acromion type,76,114,133,166 acromiohumeral distance,75,76 atrophy of teres minor,75 duration of immobilization,76 diabetes,108,148 glenoid or humeral osteoarthritis,65,148 concomitant distal clavicle excision,148 presence of subscapularis tear,65,133 and superior migration of humeral head.65 The majority of studies found that age was not associated with functional outcome,70,76,80,119,121,122,128,131,134,145,148 while one found older age to predict better functional score133 and three concluded older age to predict poorer scores.73,105,151 Similarly, gender did not predict functional outcomes in six studies,64,70,131,133,148,151 whereas three studies found males to have better73,80,105 and two studies found males to have worse100,128 outcomes compared with females. Authors’ conclusions regarding the role of tear size on functional outcomes was inconsistent across studies. Studies reported that small tear size predicted better function, 60,68,72,76,93,100,112,114,116,123,142,145,147,151 or reported no influence of tear size on functional outcome. 73,77,92,104,105,121,122,124,125,128,130,148,154,157,173 All of the studies which examined the symptom duration found no effect on functional outcomes.80,121,122,134,145,151 Authors’ conclusions for the remaining factors are displayed in Table 62.

Seventeen studies68,72,74,84,90,92,99,103,104,109,110,116,117,124,125,134,142 assessed the role of prognostic factors on cuff integrity. The studies used subgroup analysis68,72,84,92,99,103,110,116,124,125 or multiple regression analysis74,90,104,109,134,142 or non-parametric tests117 to examine the effect of various patient factors on cuff integrity, including tear size,68,72,74,92,103,104,109,110,116,117,124,125,134,142 age,74,84,90,103,110,124,125,134,142 sex,74 number of tendons torn,92,142 duration of symptoms,74,92,134 tendon retraction,110,124 preoperative strength,74,134 preoperative stiffness,134 fatty infiltration and muscle atrophy,99,104 tear pattern,84,92,110,117 biceps pathology,84,92,124 tear type,99 time to surgery,84 operative time,134 surgical learning curve,134 hand dominance,84 WCB status,74,84 and degree of occupational use.103 The authors found that the most significant factors affecting cuff integrity were age and tear size. Older age was found to be associated with recurrent tears in all studies investigating this factor74,84,90,103,110,124,125,142 but one.134 Increased tear size was found to be a significant risk factor for tendon defects in several studies,68,72,74,103,104,109,116,134,142 while four studies found no significant effect of tear size on cuff integrity.92,110,124,125 No association was found between sex74,84 or duration of preoperative symptoms74,84,92,134 on cuff integrity. Table 62 presents the authors’ conclusions for the role of the remaining prognostic factors on cuff integrity.

Sixteen studies62,64,70,72,83,84,89,92,114,116,121,128,141,148,151,160 examined the role of prognostic factors on pain. The studies used subgroup analysis62,64,70,72,83,84,92,114,116,128,141,148,151 or multiple regression analysis89,121,160 to examine the effect of various prognostic factors on pain, including age,70,83,84,121,128,148,151 sex,64,70,83,84,128,148,151 tear size,72,83,92,114,116,121,128,148,151 duration of preoperative symptoms,83,84,92,114,121,151 WCB,84,121,128 etiology of tear,83,114,121 biceps pathology or procedure,83,84,92,148 osteoarthritis,148 diabetes,148 concomitant distal clavicle excision,148 smoking,128,148,151 hand dominance,83,84 acromion morphology,83,114 tear pattern,84,92 side affected,83 location of tear,83 repair tension,89 number of tendons torn,92 preoperative strength,114 preoperative stiffness,141 BMI,151 and number of comorbidities.160 The authors’ conclusions on the role of these prognostic factors on pain were variable. Older patients were found to have significantly more pain,84 and significantly less improvement in outcome,151 in two studies, while three other studies found no association between age and pain level.70,121,128,148 Sex was found not to effect outcomes in four studies,64,70,148,151 yet one study found that men had significantly less postoperative pain than women.83 For tear size, several studies found that smaller tear size was associated with less pain than large or massive tears, yet the difference was not statistically significant72,83,116 in all but two studies.148,151 Three studies found no effect of tear size on outcomes.92,114,128 Symptom duration was consistently found not to influence the outcome.84,114,121,151 The author conclusions for other prognostic factors are presented in Table 62 below.

Ten studies72,75,83,92,121,125,141,148,162,164 examined the role of prognostic factors on range of motion. The studies used subgroup analysis72,83,92,125,141,148,162,164 or regression analysis75,121 to examine various prognostic factors including age,75,83,121,148,164 sex,75,83,148,164 tear size,72,83,92,125,148,162,164 duration of preoperative symptoms,92,121,164 biceps pathology,92,121,148 concomitant distal clavicle excision,148 osteoarthritis,148 diabetes,148 etiology of tear,121,164 WCB,121,164 time to followup,75 preoperative function,75 number of tendons torn,92 preoperative stiffness,141 hand dominance,164 tear type,164 and presence of comorbidities.164 Author conclusions regarding the prognostic factors for range of motion varied. Cofield83 reported that older age was associated with lower active range of motion, whereas the results from two studies92,148 indicated that age had no affect. Cofield83 further reported that men demonstrated significantly better active abduction than women. Four authors92,121,125,148 found that tear size had no affect on range of motion, comparatively, two72,83 studies found that smaller tears showed better range of motion outcomes after surgery than larger tear sizes. Tauro162 reported tear size was positively correlated to range of motion. Duration of preoperative symptoms was found to have no effect on postoperative range of motion. Table 62 presents authors’ conclusions for the remaining prognostic factors examined in the studies.

Thirteen studies71,74,83,86,92,101,104,105,115,121,125,141,147 assessed the role of prognostic factors on strength. The studies used subgroup analysis,71,83,86,89,92,101,125,141,147,153 multiple regression analysis,74,104,105,121 or analysis using non-parametric tests.115 The patient factors that were examined include age,74,83,105,121,153 sex,74,83,86,105 tear size,71,83,104,105,115,125,147,153 duration of preoperative symptoms,92,121 biceps pathology,92,105,121 preoperative strength,74,105 preoperative shoulder stiffness,141 number of tendons torn,92 type of tendon,101 tendon retraction,105 location,105 shape,105 fatty infiltration105 and muscle atrophy,104 etiology of tear,121 hand dominance,105 general health status,153 and WCB.121 The majority of the 13 studies investigating strength concluded that tear size affected post operative strength; however, results varied. Three studies92,105,125 found no significant effect between tear size and strength, whereas the remaining authors made no conclusions71 or found that the greater the tear size, the poorer the result achieved for postoperative strength.74,83,101,115,121,147 Authors’ conclusions for the remaining factors are displayed in Table 62.

#### Postoperative Rehabilitation Studies

Of the eleven studies evaluating the effectiveness of postoperative rehabilitation treatments, four studies (two RCTs,180,184 one retrospective cohort study181 and one BA study175) explored the role of various patient or clinical factors as prognostic factors (Table 63). The prognostic factors were examined using subgroup analysis in two studies,175,184 regression analysis in one study,180 correlation analysis in one study,181 and both subgroup and regression analysis in the remaining study.175 All studies planned the analyses a priori. Patient variables examined in the studies included age,175,180,181,184 sex,175,180,181,184 tear size,175,180,181,184 biceps pathology,181 number of comorbidities,175 smoking,175 and type of preoperative treatment.175 The role of prognostic factors was evaluated for functional outcomes in all of the studies, as well as for health-related quality of life,175 pain, range of motion, and strength.180 In one study,175 a greater number of comorbidities was found to be correlated with significantly worse health-related quality of life scores, but not with functional outcome scores. Three studies found that age, sex, and tear size were not associated with outcomes, with the exception that women had greater improvement in pain subscales,180,184 while men had greater improvement in range of motion.180 Authors’ conclusions for the remaining factors are displayed in Table 63.

Table 63 Prognostic factors in postoperative rehabilitation studies

Author, year Study design | Intervention Followup, mean (range) | Type of analysis | Outcome variable | Authors’ conclusions
Boissonnault WG,175 2007 BA | Rehabilitation protocol 13 wk (3–28) | Subgroup analysis by number of comorbidities. Multiple regression analysis controlling for age, sex, smoking, tear size, pre-op treatment. (a priori) | SF-36 DASH | A greater number of comorbidities was associated with significantly worse SF-36 scores, but not with DASH scores.
LaStayo PC,180 1998 RCT | G1: CPM G2: Manual passive ROM exercises 22 mo (6 mo–3.8 yr) | Regression analysis controlling for age, sex, and tear size (a priori). | SPADI pain ROM strength | No significant effect of age, sex, or size of tear on outcomes, except that women indicated significantly less pain than men.
Marc T,181 2009 Retrospective cohort | G1: Inpatient in rehab centre (26) G2: Private practice specializing in ‘CGE’ (38) G3: Inpatient and outpatient (16) 2 yr (minimum) | Correlation analysis controlling for age, tear size, sex biceps pathology (a priori) | CMS | Gain in CMS is not influenced by age, sex, tear size or state of biceps.
Raab MG,184 1996 RCT | G1: CPM & PT G2: PT only 3 mo | Subgroup analysis by age, sex, and tear size (a priori) | Shoulder score | Age, sex, and tear size were not associated with the overall shoulder score. For the subscores, women showed a significant improvement in the pain and men showed significant improvement in the ROM.

BA = before-and-after; CGE = Concept Global d’Epaule; CPM = continuous passive motion; DASH = Disabilities of the Arm, Shoulder and Hand; G = group; mo = month; PT = physical therapy; RCT = randomized controlled trial; ROM = range of motion; SF-36 = Short Form-36; SPADI = Shoulder Pain and Disability Index; wk = week; yr = year

#### Nonoperative Studies

Of the 10 studies examining the effectiveness of nonoperative interventions, two studies (one prospective cohort with before-and-after data188 and one BA study187) explored the role of various patient or clinical factors as prognostic factors (Table 64). The analysis of prognostic factors was specified a priori in one study188 and post hoc the other study.187 The studies used subgroup analysis to examine the effect of tear type,188 cause of tear,187 duration of symptoms,187 pain,187 sleep loss,187 and WCB status187 on functional outcome scores.187,188 Functional scores were found to be negatively correlated with preoperative sleep loss and WCB claim in one study.187 In contrast, functional improvement was shown to be independent of tear type,188 duration of symptoms, degree of pain, and cause of tear.187

Table 64 Prognostic factors in nonoperative studies

Author, year Study design | Intervention Followup, mean (range) | Type of analysis | Outcome variable | Authors’ conclusions
Hawkins RH,187 1995 BA | Exercise protocol 3.8 yr (2.6–4.6) | Subgroup analysis by WCB status, sleep loss, duration of symptoms, degree of pain, and cause of tear (post hoc) | ASES CMS | WCB claim and preoperative sleep loss was associated with unsatisfactory functional outcome. None of the other patient variables were found to predict treatment outcome.
Heers G,188 2005 Prospective cohort as BA | Home exercise program 2.7 mo (maximum) | Subgroup by tear type (a priori) | CMS | Patients showed significant functional improvement regardless of type of tear.

ASES = American Shoulder and Elbow Scale; BA = before-and-after; CMS = Constant-Murley score; mo = month; WCB = workers’ compensation board; yr = year

#### Operative vs. Nonoperative Studies

Of the five studies that examined the effectiveness of nonoperative vs. operative interventions, one retrospective cohort study197 conducted a post hoc subgroup analysis to explore the effect of age and timing of surgery on functional outcomes (Table 65). The authors found that age had no significant effect on function, as measured by the JOA scale. Time between symptom onset and surgery affected outcomes, where intervals longer than 12 months were associated with postoperative difficulties.

Table 65 Prognostic factors in operative vs. nonoperative studies

Author, year Study design | Intervention Followup, mean (range) | Type of analysis | Outcome variable | Authors’ conclusions
Yamada N,197 2000 Retrospective cohort | G1: Steroid injection, stretching, strengthening G2: Open RCR 4 yr (12 mo–23 yr) | Subgroup analysis by age and timing of surgery (post hoc) | JOA | Age had no significant effect on function, as assessed by the JOA scale. Time between symptom onset and surgery was associated with outcomes, where intervals longer than 12 months were associated with postoperative difficulties.

G = group; JOA = Japanese orthopaedic association; mo = month; RCR = rotator cuff repair; yr = year