# Introduction

## Condition and Prevalence

The rotator cuff (RC) is comprised of four muscle-tendon units (supraspinatus, infraspinatus, subscapularis, and teres minor) that originate on the scapula and combine to form a covering or “cuff” around the top of the humeral head.1 The RC helps to stabilize the humeral head within the shoulder joint and aids in powering the upper extremity through the movements of flexion, extension, abduction, adduction and external and internal rotation.

A “tear” is the term given to a discontinuation in either one or more of the tendons or muscles that make up the RC; tears are classified as either partial or full thickness. Partial-thickness tears involve only a portion of the tendon thickness and do not lead to retraction of the muscle-tendon unit.6 In contrast, full-thickness tears refer to a complete discontinuity of RC fibers, resulting in contact between the articular and bursal spaces. RC tears are rated as small (<1 cm), medium (1–3 cm), large (3–5 cm), and massive (>5 cm). Tears that involve two or more tendons may also be classified as massive and may require more complex reconstruction.7 The degree of functional impairment of the muscle depends in part on the size of the tear.8

The RC can be torn from a single traumatic injury or, more commonly, a tear may result from overuse of the muscles and tendons over a period of years, leading to degeneration of the tendon that progresses to a tear.9 A cuff tear may also occur concurrently with another injury to the shoulder, such as a fracture or dislocation, or be the result of poor vascular supply, impingement, glenohumeral instability, scapulothoracic dysfunction or congenital abnormalities, such as os acromiale.10 RC tears also occur in the shoulders of overhead or throwing athletes, whose throwing motion involves maximum abduction and external rotation making the shoulder vulnerable to injury from repetitive high energy forces.11 Once a tear occurs, it is unlikely to heal without treatment.6 Left untreated, large tears may result in chronically retracted muscle-tendon units that undergo fatty degeneration resulting in weakness, a potentially irreversible process.9

The incidence of RC tears is expected to increase with the growth of an aging population that is more active and less willing to accept functional limitations.12 Magnetic resonance imaging (MRI) studies have shown partial or complete tears in only 4 percent of patients under 40 years of age compared with 54 percent of patients over 60 years of age.2 Larger tear size and occurrence of bilateral RC tears also increase with age.13 Although large proportion of patients with RC tears are asymptomatic, research has shown that over 50 percent of individuals with asymptomatic RC tears will develop pain over an average of 2.8 years.10

Although not a life-threatening condition, RC tears may cause significant pain, weakness, and limitation of motion.1 A shoulder disorder can increase functional dependency in the elderly due to difficulties in completing activities of daily living.13 In younger adults, this morbidity may also lead to significant disability, including absenteeism from work and lost productivity. The impact of RC disease on lost productivity is reflected in the high costs associated with shoulder injuries in the workers’ compensation system, and has been found to be the second most common cause after back pain for time away from work in manual laborers.14–16 According to data from the United States Department of Labor, 253,670 occupational shoulder injuries were reported in 2007. The average time off of work due to occupational shoulder injuries ranged from 4.3 to 7.5 days; however, 41.5 percent of occupational shoulder injuries required more than 31 days away from work in 2007.^17^ In addition, severe pain may affect sleep. The impact of RC disease on health-related quality of life, as measured by the SF-36, is comparable to the effects of hypertension, myocardial infarction, congestive heart failure, diabetes mellitus, and clinical depression.18

## Diagnosis and Treatment

Diagnosis of an RC tear involves a complete history, appropriate clinical examination, and a comparison of the involved shoulder to the uninjured side. The shoulder is palpated to identify areas of tenderness and range of motion of the shoulder is assessed both actively and passively.19 RC strength is evaluated and a number of provocative maneuvers are completed to assist in the development of a differential diagnosis. Since most clinical tests for rotator cuff pathology have been shown to have poor diagnostic accuracy20 and give poor estimates of cuff tear size,21 diagnostic imaging should be employed as part of the preliminary work-up for chronic shoulder pain. Radiographs may be used initially followed by MRI, arthrography, computed tomography (CT) or ultrasound for further evaluation and clarification of possible pathology.19

Two treatment modalities, nonoperative and operative, are used in an attempt to relieve pain and restore movement and function of the shoulder.3 Most patients initially undergo 6 weeks to 3 months of nonoperative treatment; however, surgical repair may be indicated early on in the appropriate patient with a traumatic RC injury and a significant functional deficit.22 The most common nonoperative interventions include pain management (medications and injections), rest from activity, and a variety of treatments, both passive and active, delivered by physical therapists. Success rates with nonoperative treatments vary from less than 50 percent to greater than 90 percent; however, studies have used a variety of interventions and evaluation tools.22

Modalities used to decrease pain include heat or cold, ultrasound, and iontophoresis,13,23 as well as medications such as acetaminophen, nonsteroidal anti-inflammatory drugs (NSAIDs), and corticosteroid injections. When pain is controlled the patient can participate in physical therapy exercises designed to increase shoulder flexibility and strength. These exercises are designed to return the shoulder to optimal functioning through improvements in range of motion, proprioception and strength.23 When other nonoperative modalities have failed to reduce pain (e.g., relative rest, activity modification, physical therapy, and NSAIDs), corticosteroid injections combined with a local anesthetic may be used.24 Controversy exists regarding the benefit of corticosteroid injections in the treatment of RC tears. Study results investigating the efficacy of injections vary, and it is unclear if corticosteroid injections provide significant benefit to the patient over treatment with NSAIDs.13,23

Failing nonoperative treatment, there are three surgical approaches to rotator cuff repair (RCR): open, mini-open, and arthroscopic, the last two of which have evolved throughout the last decade.25 The first surgical repair of a torn RC was performed in 1909 by Ernest Codman.26 In 1972, Charles Neer developed an open surgical technique, which uses a large (9-centimetre) incision over the shoulder from the anterior edge of the acromion to a point just lateral to the coracoid. The deltoid is split (5 centimetres) and dissected from the anterolateral acromion and the distal clavicle. This allows for adequate visualization of the RC tear. A small wedge-shaped piece of bone is removed from underneath the acromion, as is the coracoacomial ligament. In the case of acromioclavicular osteophytes and acromioclavicular arthritis, up to 2 centimetres of the distal clavical may be excised along with any prominences on the acromial side. Careful reattachment of the deltoid to the acromion and clavicle is required following the repair.27

A mini-open repair combines an open technique with arthroscopy to reduce the size of the incision required to perform the repair. Initially, portals are created to allow the insertion of the arthroscope and arthroscopic tools. To perform the repair, an additional incision is created to visualize the RC. The surgeon reaches the RC tear by splitting the deltoid muscle in line with its fibers rather than releasing it from the acromion. A temporary suture is placed in the deltoid to prevent further tearing of the muscle and damage to the axillary nerve while the RCR is completed. Mini-open repair is currently considered best suited for small and medium tears, but may be used for larger tears.26 The mini-open approach reduces the chance of deltoid injury and failure of the deltoid repair that may occur with a traditional open technique.27

Arthroscopic surgery uses specially designed instruments (a camera, a fiberoptic light source, and the instruments required for the repair) that are inserted into the joint through a series of small incisions or portals. Modern arthroscopic techniques now allow for not only the evaluation of both the bursal and articular surfaces of the RC, as well as other structures within the shoulder joint, but also allow for definitive treatment of the injured RC.11 Most authors agree that indications for arthroscopic repair are similar to those for open repair.27 Arthroscopic repair has a number of benefits over open repair including: shorter hospital stays, lower levels of pain, better cosmetic outcomes, preservation of the deltoid muscle, and direct inspection of the glenohumeral joint.27

Regardless of whether surgery is open, mini-open, or arthrocopic, treatment may involve any combination of RCR, debridement, and acriomplasty. The repair itself involves suturing the torn edges of the involved tendon(s) together and repair of the tendon back to the humeral head. A full or partial repair may be performed, depending on the severity of the tear. As its name implies, full repair is the complete repair of the tear. When a complete repair is not feasible, such as when the tear is extremely large, a partial repair may be performed in order to restore adequate function and delay the progression of the tear.8 Debridement involves removing loose fragments of tendon, bursa, and other debris from the space in the shoulder where the RC moves.11 Acromioplasty involves the removal of bone from the underside of the anterolateral acromion (the tip of the shoulder blade), thus creating more room in the subacromial space, and decreasing mechanical impingement of the acromion on the RC. Subacromial decompression combines an acromioplasty with the removal of the subacromial bursa and, in some cases, removal of the coracoacromial ligament. Though performed on their own, debridement, acromioplasty and/or subacromial decompression are often performed in combination with an RCR.

Other procedures that may accompany RCR include labral repair, biceps tenotomy or tenodesis, and acromioclavicular joint arthroplasty. A labral repair involves the surgical repair of the labrum, a cuff of cartilage that circles the glenoid or socket of the shoulder and helps to stabilize the shoulder. A labral tear may occur as a result of trauma to the shoulder or fray and tear as part of the aging process. A biceps tenodesis detaches the tendon from its insertion at the top of the labrum and reattaches the tendon in the bicipital groove at the anterolateral aspect of the proximal humerus. Biceps tenotomy involves the release of the biceps tendon from its attachment without reattachment to the proximal humerus, thus allowing the tendon to retract distally in the upper arm outside of the shoulder joint. These procedures are performed for partial tears of the biceps tendon that cannot be repaired, bicep tendons that are subluxed or dislocated, or in situations when tears of the superior glenoid labrum cannot be repaired.

The final step in the surgical treatment of RC tears is a program of rehabilitation, the development of which is based on the type of surgery, size of tear, tissue quality, fixation methods, and patient characteristics.3 Following surgery, the shoulder is generally immobilized using a sling, both as a comfort measure and as a reminder to the patient to avoid use of the shoulder. Passive motion, continuous passive motion (the continuous movement of the repaired shoulder by a machine), and unassisted exercises are then used to restore range of motion and muscle strength, and to re-establish shoulder stability and function. Strengthening exercises are generally added gradually with progressive levels of resistance as sudden increases in exercise demands may lead to a failure of the repair. The primary goal of rehabilitation should be to protect the cuff repair, promote healing, restore passive and active motion, and increase muscular strength.3

It has been proposed that earlier surgical intervention may result in better outcomes, earlier return to work and decreased costs;4,5 thus, clinicians face the difficult decision of when to forego attempts at nonoperative management in favour of surgical treatment. Despite the significant morbidity and cost associated with RC tears, there remains much uncertainty regarding the comparative effectiveness of the many nonoperative and operative treatment options.

## Outcome Assessment Scales

A wide variety of outcome measures have been used to evaluate the efficacy of RC treatments by assessing changes in patient function over the study period. A list of the frequently reported outcome measures is provided in Table 1. The majority of scales used in the RC literature are disease-specific questionnaires developed for the assessment of the shoulder; however, generic scales (e.g., SF-36) have also been used. The scales can broadly be classified into health-related quality of life and functional outcome measures. Health-related quality scales are developed with the intent of assessing patients’ perception of the impact of their condition on their physical, social, psychological/emotional, and cognitive state. Functional outcome measures evaluate a patient’s ability to perform activities of daily living and frequently incorporate clinically assessed components, such as range-of-motion or strength.

Table 1 Summary of most frequently reported outcome measures

Health-related quality of life scales
Outcome measure | Domains | Scaling | Psychometric properties (validity; reliability; responsiveness)
Rotator Cuff Quality of Life (RC-QOL)28 Patient self-reported | Symptoms & physical complaints (16 items) Work-related concerns (4 items) Sports & recreation (4 items) Lifestyle issues (5 items) Social & emotional issues (5 items) | 34 items, each rated on a 100-point VAS. Total score ranges from 0 (worst) to 100 (best). | Correlation with SF-36 (r_p_=0.778), ASES (r_p_=0.842),28 Correlation with WORC (r_s_≥ 0.70);29 ICC 0.97^*^ (test-retest reliability presented as avg error difference of 5.05%);28 SRM 1.43,^29^ MCID NR
Short Form-36 (SF- 36)30 Patient self-reported | Physical function (10 items) Role-physical (4 items) Bodily pain (2 items) General health (5 items) Vitality (4 items) Social function (2 items) Role-emotional (3 items) Mental health (5 items) | Items are scored using 5-level response options. Domains are summed & translated to two aggregate summary measures (physical health & mental health), with scores ranging from 0 (worst health) to 100 (best health) | Moderate correlation with shoulder instruments (SPADI, SST, ASES) 0.58≤ r_p_≤0.72;^31^ Cronback’s α≥ 0.85; ICC≥ 0.80 for all dimensions except social functioning (0.76);30 Low responsiveness: SRM: PCSS 1.0, MCSS 0, subscales on bodily pain: 1.1^32^
Western Ontario Rotator Cuff Index (WORC)33 Patient self-reported | Physical Symptoms (6 items) Sports/Recreation (4 items) Work (4 items) Lifestyle (4 items) Emotions (3 items) | 21 items, each rated on a 100-point VAS. Scores presented in raw form or converted to a percentage. Best score (no decrease in shoulder-related QOL) is 100% (raw score=0). Worst score (extreme decrease in shoulder-related QOL) is 0% (raw score=2100). | As a discriminative instrument, correlated most strongly with ASES (r=0.68) & DASH (r=0.63); as a evaluative instrument, correlated with ASES (r=0.75) & UCLA (r=0.65);33 ICC 0.96;^33^ SRM 1.44,^29^ MID change in total score of 245.26 (11.7%), moderate difference change in total score of 371.3 (17.68%), and large difference change in total score of 773.4 (36.82%)33
Functional outcome scales: self-reported
Outcome measure | Domains | Scaling | Psychometric properties (validity; reliability; responsiveness)
Disabilities of the Arm, Shoulder and Hand (DASH)34,35 Patient self-reported | Items related to activities of daily living, pain, weakness & function. * Optional modules to assess: high performance sport/ music or work. | 30 items, rated on a 5-point Likert scale. Total score ranges from 0 points (best) to 100 points (worst). | Strong correlation (r≥ 0.70) with commonly used scales, except SF-36 and clinical variables (r=0.30–0.70);36 ICC 0.82–0.98, weighted avg 0.90, SEM 2.84–5.22, weighted avg 4.5, MDC (90% CI) 6.6–12.2, weighted avg 10.5;^36^ Responsiveness similar to other joint-specific measures. ES 0.4–1.4, weighted avg 1.1, SRM 1.1–1.7, weighted avg 1.3, MCID 10.2^36^
Insalata Shoulder Rating Questionnaire (SRQ)37 Patient self-reported | Global Assessment Domain (10-point VAS) Pain (4 items) Activities of Daily Living (6 items) Recreation & Athletic Activities (3 items) Work (4 items) Satisfaction (1 item) Importance (patients ranks the 2 areas most important for improvement) | 18 items rated using 5-level response options; one item rated on a 10-point VAS. Total scores range from 17 (worst) to 100 (best) points & are calculated using a weighting system. | High correlation with the Arthritis Impact Measurement Scales 2 (0.56–0.89);37 Cronbach’s α 0.86, Kappa 0.73–0.97;^37^ SRM 1.9,^37^ MCID 13^38^
Simple Shoulder Test (SST)39 Patient self-reported | Items related to activities of daily living. | 12 functional task questions answered yes=1 or no=0. Total score is the number of “yes” responses; Best score 12/12, represents no disability; Total score range is 0–12 (transformed to a percentage). | Strong correlation (r≥0.70) with commonly used scales, except SF-36 and clinical variables (r=0.30–0.70);36 Cronbach’s α 0.85, SEM (95% CI) 11.65 (22.8),40 ICC 0.97–0.99, weighted avg 0.98, MDC not defined;36 ES 0.8, SRM 0.8–1.8, weighted avg 0.9, MCID not defined36
Shoulder Pain and Disability Index (SPADI)41,42 Patient self-reported | Pain (5 items) Disability (8 items) | 13 items each scored on a scale from 0 to 10. Total score ranges from 0 points (best) to 100 points (worst) | Strong correlation (r≥ 0.70) with commonly used scales, except SF-36 and clinical variables (r=0.30–0.70);36 Cronbach’s α 0.95,0.96, ICC>0.85, 0.85–0.95, weighted avg 0.89, SEM 6.2–7.8, MDC (90% CI) 18.1;^36^ ES 1.2–2.1, weighted avg 1.6, SRM 1.1–1.7, weighted avg 1.3, MCID 8, 13.2^36,38^
Functional outcome scales: self-reported and clinician-assessed
Outcome measure | Domains | Scaling | Psychometric properties (validity; reliability; responsiveness)
American Shoulder and Elbow Surgeons (ASES)43,44 Patient self-reported & clinician-assessed | Pain (1 item, 10-point VAS) Activities of daily living (10 items, rated on 4-point scale) ROM–active & passive Physical signs (0 to 3) Strength (0 to 5 grade) Instability (0 to 3) | Shoulder score derived from self- reported components (pain & cumulative activities of daily living score), ranging from 0 points (worst) to 100 points (best). | Strong correlation (r≥0.70) with commonly used scales, except SF-36 and clinical variables (r=0.30–0.70);36 Cronbach’s α 0.86, ICC>0.84, ICC 0.84–0.96, weighted avg 0.91,^36^ MDC (90% CI) 9.4, SEM 6.7;^45^ ES 0.9–3.5, weighted avg 1.4, SRM 0.5–1.6, weighted avg 1.1, MCID 6.4^36,45^
Japanese Orthopaedic Association (JOA) Patient self-reported & clinician-assessed | Pain (30 points) Function (strength in abduction, endurance, activities of daily living) (20 points) ROM (30 points) Radiographic evaluation (5 points) Joint stability (15 points) | Total score ranges from 0 points (worst) to 100 points (best). | Spearman’s rank correlation coefficient between observers: r>0.78
University of California Los Angeles (UCLA)46,47 Patient self-reported & clinician-assessed | Pain (10 points) Function (10 points) ROM (5 points) Strength (5 points) Patient satisfaction (5 points) | Maximum 35 points (best). | Fair correlation with CMS (r_s_=0.66) & SST(r_s_=0.76);47 ICC: pain (0.59–0.78), function (0.51–0.89), satisfaction (0.79)48
University of Pennsylvania Shoulder Score (PENN)49 Patient self-reported & clinician-assessed | Pain (30 points) Satisfaction Function (20 items, 4-category Likert scale) ROM Strength | Maximum 100 points for both the self-reported and clinician- assessed measures; higher scores indicate greater (best) function | Strong correlation with CMS (r=0.85) & ASES (r=0.87); Cronbach’s α 0.93, ICC (95% CI) 0.94 (0.89–0.97), MDC (90% CI) 8.5, SEM (90% CI) 12.1 ES 1.01, SRM 1.27, MCID 11.4^49^

ASES = American Shoulder and Elbow Surgeons scale; avg = average; CMS = Constant-Murley score; DASH = Disabilities of the Arm, Shoulder and Hand; ES = effect size; ICC = interclass correlation coefficient; JOA = Japanese Orthopaedic Association scale; MCID = minimal clinically important difference; MCSS = mental component summary score; MDC = minimal detectable change; MID = minimal important difference; PCSS = physical component summary score; PENN = University of Pennsylvania Shoulder Score; RC-QOL = Rotator Cuff Quality of Life questionnaire; ROM = range of motion; SEM = standard error of the measure; SF-36 = Short Form-36; SST = Simple Shoulder Test; SPADI = Shoulder Pain and Disability Index; SRM = standardized response mean (mean change score/SD change score); SRQ = Shoulder Rating Scale; UCLA = University of California Los Angeles scale; UEFI = upper extremity functional index; VAS = visual analogue scale; WORC = Western Ontario Rotator Cuff Index

* Calculated by UAEPC using raw data from Hollinshead et al.

Three health-related quality of life measures were used in the studies reviewed in this report: the Rotator Cuff Quality of Life (RC-QOL) scale, the Short-Form-36 (SF-36) and the Western Ontario Rotator Cuff (WORC) index. These self-reported scales assess similar domains, such as pain, physical symptoms, social and emotional functioning. The RC-QOL and SF-36 are scored on a scale of 0 to 100 points, where higher scores indicate better quality of life, while the WORC Index provides a score of up to 2,100 points with higher scores indicating poorer outcomes. There is evidence to support the reliability and convergent validity of each of the scales.

Nine scales assessing functional outcomes were frequently used in the included studies. Of these, four scales were entirely patient self-reported, while the remaining five included both self-reported and health professional-assessed components. The majority of the measures assessed pain, activities of daily living, range of motion and strength. Less commonly evaluated domains included patient satisfaction, joint stability, and recreation activities. Most scoring systems calculated an overall score out of 100 points, however the distribution of the points by domain varied across the tools. Psychometric properties also varied across the scales. The majority of the scales have evidence to support their reliability. In addition, some scales demonstrated strong correlations with other commonly used shoulder assessment scales.

## Objectives

The objective of this review is to provide a comprehensive synthesis of the evidence examining the effectiveness of nonoperative and operative interventions for the treatment of RC tears. The report is intended for a broad audience, including professional societies developing clinical practice guidelines, patients and their care providers, as well as researchers conducting studies on treatments of this condition. Outcomes of interest include health-related quality of life, shoulder function, time to return to work, cuff integrity, pain, range of motion and strength of the shoulder. The key questions investigated in this report are presented below, alongside an analytic framework (Figure 1).

Figure 1 Analytic framework corresponding to the key questions

Diagram depicting the relationship among the population, interventions, comparators, and outcomes as they relate to the key questions of the review. Interventions include operative and non-operative treatments. Outcomes of interest include health-related quality of life, shoulder function, time to return to work, cuff integrity, pain, range of motion and strength of the shoulder.

## Key Questions

The following key questions were investigated for a population of adult patients with partial- and full-thickness RC tears:

1. Does early surgical repair compared to late surgical repair (i.e., nonoperative intervention followed by surgery) lead to improved health-related quality of life, decreased disability, reduced time to return to work/activities, higher rate of cuff integrity, less shoulder pain, and increased range of motion and/or strength?
2. What is the comparative effectiveness of operative approaches (e.g., open surgery, mini-open surgery, arthroscopy) and postoperative rehabilitation on improved health-related quality of life, decreased disability, reduced time to return to work/activities, higher rate of cuff integrity, less shoulder pain, and increased range of motion and/or strength?
  a. Which operative approach should be used for different types of tears (e.g., partial-thickness, full-thickness, small, medium, large or massive, with or without fatty infiltration of muscle tissue)?
3. What is the comparative effectiveness of nonoperative interventions on improved health-related quality of life, decreased disability, reduced time to return to work/activities, higher rate of cuff integrity, less shoulder pain, and increased range of motion and/or strength? Nonoperative interventions include, but are not limited to, exercise, manual therapy, cortisone injections, acupuncture, other treatments and modalities typically delivered by physical therapists, osteopaths and chiropractors.
  - b. Which nonoperative treatment approach should be used for different types of tears (e.g., partial-thickness, full-thickness, small, medium, large or massive, with or without fatty infiltration of muscle tissue)?
4. Does operative repair compared to nonoperative treatment lead to improved health-related quality of life, decreased disability, reduced time to return to work/activities, higher rate of cuff integrity, less shoulder pain, and increased range of motion and/or strength?
5. What are the associated risks, adverse effects, and potential harms of nonoperative and operative therapies?
6. Which demographic (e.g., age, gender, ethnicity, comorbidities, workers’ compensation claims) and clinical (e.g., size / severity of tear, duration of injury, fatty infiltration of muscle) prognostic factors predict better outcomes following nonoperative and operative treatment?
  - c. Which (if any) demographic and clinical factors account for potential differences in surgical outcomes between patients who undergo early vs. delayed surgical treatment?